# AUTHORS | CONTRIBUTORS | REVIEWERS

Assessment Managers (Lead Authors)
Xabier Arzuaga (https://orcid.org/0000-0002-7978-5431), Ph.D. | U.S. EPA/ORD/CPHEA
Ingrid L. Druwe (https://orcid.org/0000-0002-0591-0295), Ph.D. | U.S. EPA/ORD/CPHEA
Authors
Thomas F. Bateson (https://orcid.org/0000-0003-1355-5745), Sc.D., M.P.H. | U.S. EPA/ORD/CPHEA
J. Allen Davis (https://orcid.org/0000-0002-3238-3849), M.S.P.H. | U.S. EPA/ORD/CPHEA
Michael Dzierlenga (https://orcid.org/0000-0001-7010-6191), Ph.D. | U.S. EPA/ORD/CPHEA
Andrew Kraft (https://orcid.org/0000-0003-3630-6741), Ph.D. | U.S. EPA/ORD/CPHEA
Alexandra L. Lee (https://orcid.org/0000-0002-1776-3149), Ph.D. | U.S. EPA/ORD/CPHEA
Elizabeth Radke (https://orcid.org/0000-0002-2504-2405), Ph.D. | U.S. EPA/ORD/CPHEA
Hongyu Ru (https://orcid.org/0000-0002-4324-8984), Ph.D. | U.S. EPA/ORD/CPHEA
Paul Schlosser (https://orcid.org/0000-0002-9699-9108), Ph.D. | U.S. EPA/ORD/CPHEA
Shana White (https://orcid.org/0000-0001-9497-0849), Ph.D. | U.S. EPA/ORD/CPHEA
John Michael Wright (https://orcid.org/0000-0001-6813-9760), Sc.D. | U.S. EPA/ORD/CPHEA
Jay Zhao (https://orcid.org/0000-0001-7600-8840), Ph.D. | U.S. EPA/ORD/CPHEA
Jason C. Lambert (https://orcid.org/0000-0003-0549-4241), Ph.D. | U.S. EPA/ORD/CCTE
Contributors
Michelle M. Angrish (https://orcid.org/0000-0002-4956-4806), Ph.D. | U.S. EPA/ORD/CPHEA
Laura V. Dishaw (https://orcid.org/0000-0003-1609-8922), Ph.D. | U.S. EPA/ORD/CPHEA
Mary Gilbert (https://orcid.org/0000-0001-8916-8851), Ph.D. | U.S. EPA/ORD/CPHEA
Barbara Glenn, Ph.D. (retired) | U.S. EPA/ORD/CPHEA
Christopher Lau (https://orcid.org/0000-0002-6391-9677), Ph.D. | U.S. EPA/ORD/CPHEA
Geniece M. Lehmann (https://orcid.org/0000-0002-7172-4175), Ph.D. | U.S. EPA/ORD/CPHEA
Andrew Hotchkiss (https://orcid.org/0000-0002-7197-959X), Ph.D. | U.S. EPA/ORD/CPHEA
Anuradha Mudipalli (https://orcid.org/0009-0008-9589-2254), Ph.D. | U.S. EPA/ORD/CPHEA
Kathleen Newhouse (https://orcid.org/0000-0002-7193-0876), Ph.D. | U.S. EPA/ORD/CPHEA
Pamela D. Noyes (https://orcid.org/0000-0003-1654-4056), Ph.D. | U.S. EPA/ORD/CPHEA
Katherine L. O’Shaughnessy (https://orcid.org/0000-0002-5167-8554), Ph.D. | U.S. EPA/ORD/CPHEA
Kristen Rappazzo (https://orcid.org/0000-0002-9939-0883), Ph.D. | U.S. EPA/ORD/CPHEA
Susan Makris (https://orcid.org/0000-0003-1358-7384), Ph.D. (retired) | U.S. EPA/ORD/CPHEA
Tammy Stoker (https://orcid.org/0000-0003-0455-2315), Ph.D. | U.S. EPA/ORD/CPHEA
Andre Weaver (https://orcid.org/0000-0001-8580-6350), Ph.D. | U.S. EPA/ORD/CPHEA
Erin Yost (https://orcid.org/0000-0001-8615-9204), Ph.D. | U.S. EPA/ORD/CPHEA
Todd Zurlinden (https://orcid.org/0000-0003-1372-3913), Ph.D. | U.S. EPA/ORD/CPHEA
Chris Corton (https://orcid.org/0000-0002-6197-2036), Ph.D. | U.S. EPA/ORD/CCTE
Stephanie Kim (https://orcid.org/0000-0003-2988-3700), Ph.D. (former) | U.S. EPA/Region 2
Andrew Rooney (https://orcid.org/0000-0002-1756-5185), Ph.D. | DTT/NIEHS
Kyla Taylor (https://orcid.org/0000-0002-5430-4224), Ph.D. | DTT/NIEHS
Dori Germolec (https://orcid.org/0000-0003-4072-1956), Ph.D. | DTT/NIEHS
Alexis Agbai | Oak Ridge Associated Universities (ORAU) Contractor
Timothy Decoff | Oak Ridge Associated Universities (ORAU) Contractor
Angela Scafidi (former) | Oak Ridge Associated Universities (ORAU) Contractor
Robyn B. Blain (https://orcid.org/0000-0002-1859-5554), Ph.D. | ICF
Alexandra E. Goldstone (https://orcid.org/0000-0003-2304-9731), M.P.H. | ICF
Alexander J. Lindahl (https://orcid.org/0000-0002-7350-5929), M.P.H. | ICF
Project Management and Production Team
Jack Rehmann | U.S. EPA/ORD/CPHEA
Ryan Jones | U.S. EPA/ORD/CPHEA
Dahnish Shams | U.S. EPA/ORD/CPHEA
Avanti Shirke | U.S. EPA/ORD/CPHEA
Jessica Soto Hernandez | U.S. EPA/ORD/CPHEA
Vicki Soto | U.S. EPA/ORD/CPHEA
Samuel Thacker | U.S. EPA/ORD/CPHEA
Garland Waleko | U.S. EPA/ORD/CPHEA
Grace Kaupas (former) | Oak Ridge Associated Universities (ORAU) Contractor
Rebecca Schaefer | Oak Ridge Associated Universities (ORAU) Contractor
Jacqueline Weinberger (former) | Oak Ridge Associated Universities (ORAU) Contractor
Executive Direction
Wayne Cascio, M.D., FACC | CPHEA Center Director
V. Kay Holt, M.S. | CPHEA Deputy Center Director
Samantha Jones, Ph.D. | CPHEA Associate Director
Kristina Thayer, Ph.D. | CPAD Division Director
Andrew Kraft, Ph.D. | CPAD Associate Division Director, IRIS PFAS Team Lead
Paul White, Ph.D. | CPAD Senior Science Advisor
Ravi Subramaniam, Ph.D. (retired) | CPAD Senior Science Advisor
Shannon Hanna, Ph.D. | CPHEA/CPAD/Toxic Effects Assessment (DC) Branch Chief
Janice Lee, Ph.D. | CPHEA/CPAD/Toxic Effects Assessment (RTP) Branch Chief
Glenn Rice, Sc.D. | CPHEA/CPAD/Science Assessment Methods Branch Chief
Viktor Morozov, Ph.D. | CPHEA/CPAD/Quantitative Assessment Branch Chief
Vicki Soto, B.S. | CPHEA/CPAD/Assessment Management Branch Chief
Review
CPAD Executive Review Committee
Kristina Thayer | CPAD Division Director
Paul White | CPHEA/CPAD/Senior Science Advisor
Janice Lee | CPHEA/CPAD/Toxic Effects Assessment (RTP) Branch Chief
Glenn Rice | CPHEA/CPAD/Science Assessment Methods Branch Chief
Ravi Subramaniam (retired) | CPHEA/CPAD/Toxic Effects Assessment (DC) Branch Chief
Karen Hogan | CPHEA/CPAD/Emeritus
Alan Stern | NJDEP (retired), Contractor

## Agency Review

This assessment was provided for review to scientists in EPA’s program and regional offices. Comments were submitted by:

- Office of the Administrator/Office of Children’s Health Protection
- Office of Air and Radiation/Office of Air Quality and Standards
- Office of Land and Emergency Management
- Office of Water
- Region 1, Boston, MA
- Region 3, Philadelphia, PA
- Region 4, Atlanta, GA
- Region 8, Denver, CO

## Interagency Review

This assessment was provided for review to other federal agencies and the Executive Office of the President (EOP). Comments were submitted by:

- Department of Defense (DoD)
- Department of Health and Human Services
  - Agency for Toxic Substance and Disease Registry
  - National Institute for Occupational Safety and Health
  - National Institute of Environmental Health Sciences
- Executive Office of the President
  - Council on Environmental Quality
  - Office of Information and Regulatory Affairs
  - Office of Science and Technology Policy
- United States Department of Agriculture