# 5 DERIVATION OF TOXICITY VALUES

## 5.1 NONCANCER AND CANCER HEALTH EFFECT CATEGORIES CONSIDERED

The available evidence indicates that oral exposure to perfluorohexanesulfonic acid [PFHxS] and its related salts is likely to cause adverse immune effects in humans on the basis of the evidence presented in human studies and adverse thyroid effects on the basis of the evidence presented in animal toxicity studies. The dose levels associated with these two identified hazards were considered for the derivation of reference doses (RfDs) as presented below. The available evidence suggests but is not sufficient to infer that PFHxS exposure may result in developmental, neurodevelopmental, cardiometabolic, and hepatic effects. Given the uncertainty in these latter conclusions, ultimately no toxicity values were derived for these health effects. A dose-response assessment is typically not performed for health effect judgments of “evidence suggests,” although when the database contains at least one well-conducted study, quantitative analyses may still be useful for some purposes, such as providing a sense of the magnitude and uncertainty of estimates for health effects of concern, ranking potential hazards, informing responses in potentially susceptible populations and lifestages, or setting research priorities (U.S. EPA, 2005, 2020). The available evidence on PFHxS-induced developmental effects includes high confidence epidemiological studies in which the observed outcome (low birth weight) occurs during a susceptible lifestage and is associated with increased lifetime risk for developing a variety of adverse health conditions such as type 2 diabetes, cardiovascular disease, neurodevelopmental disorders, and renal disease (Tian et al., 2019a; Reyes and Mañalich, 2005; Hack et al., 1995). The evidence for PFHxS-induced hepatic effects was also compelling despite being categorized as evidence suggests, with strong suggestive evidence in both humans and animals. Well-conducted epidemiological studies report consistent associations with serum ALT, though with potential confounding by other PFAS as a key source of uncertainty. This was selected as the most consistent human endpoint and over animal studies due to the preference for human evidence when available (as described elsewhere). Thus, for comparison purposes during toxicity value derivation for the identified (likely) PFHxS hazards of immune and thyroid effects, points of departure (PODs) were estimated for developmental (i.e., birth weight) and hepatic (i.e., serum ALT) effects (see Section 5.2.1). No other endpoints were considered for the derivation of toxicity values.

There are no available studies to inform the potential for PFHxS to cause adverse health effects via inhalation exposure precluding the derivation of reference concentration (RfC) (see Section 5.2.3). Likewise, evidence pertaining to the evaluation of carcinogenicity was considered inadequate to assess carcinogenic potential of PFHxS in humans, precluding the derivation of cancer toxicity values via any exposure route (see Section 5.3).

## 5.2 NONCANCER TOXICITY VALUES

Noncancer toxicity values, including reference doses (RfDs) for oral exposure and reference concentrations (RfCs) for inhalation exposure, are estimates of an exposure for a given duration to the human population (including susceptible subgroups and/or lifestages) that are likely to be without an appreciable risk of adverse health effects over a lifetime. The RfD derived in Section 5.2.1 corresponds to chronic, lifetime exposure and is the primary focus of this document. In addition, a less-than-lifetime, subchronic toxicity value (referred to as a “subchronic RfD”), which corresponds to exposure durations ranging from a month to 10% of the life span in humans, is derived in Section 5.2.2. Subchronic toxicity values may be useful for certain decision-making contexts (e.g., site-specific risk assessments with less-than-lifetime exposures). Both RfD and subchronic RfD derivations include organ-/system-specific RfDs (osRfDs) associated with health effect-specific PODs considered for use in deriving the RfD (or subchronic RfD). As with the subchronic RfD, osRfDs can be useful for certain decision-making contexts (e.g., cumulative risk assessment). Subsequent decisions related to dosimetric extrapolation, application of uncertainty factors, and confidence in toxicity values are discussed below. No information exists to inform the potential toxicity of inhaled PFHxS or derive an RfC; this decision is discussed in Section 5.2.3.

### 5.2.1 Oral Reference Dose (RfD) Derivation

#### Study/Endpoint Selection

Data sufficient to support dose-response analyses and POD calculations for oral exposure to PFHxS or its salts were available for both identified human health hazards: thyroid and immune effects. As mentioned above, although a definitive health hazard was not identified, a POD was also calculated for developmental and hepatic effects because the evidence base for PFHxS includes well-conducted epidemiological studies albeit with some uncertainty. In addition, derivation of a POD for developmental and hepatic outcomes was considered informative of the potential magnitude of effects relevant to susceptible populations and lifestages and thus might inform toxicity value derivation for thyroid or immune effects.

Rationales for study selection, details of the POD calculations, and toxicity value estimation, as well as determination of confidence in the derived toxicity values, are detailed in this section. The general considerations used to prioritize studies for estimating PODs for potential use in derivation of toxicity values are described in the IRIS PFAS Protocol (see Appendix A). Well-conducted (i.e., high or medium confidence) human studies that were deemed influential to the hazard conclusions were prioritized for POD derivation and compared with PODs derived from well-conducted animal studies when possible. Such human studies were available for developmental and immunotoxicity effects.

A summary of endpoints and rationales considered for toxicity value derivation is presented below.

##### Thyroid effects

Human studies provide conflicting evidence as to the potential effects of PFHxS on thyroid outcomes (e.g., thyroid hormone levels). While a few studies did suggest an association between increasing PFHxS exposure levels and decreased circulating thyroid hormones (i.e., T4) or subclinical thyroid disease, these associations were not consistent across studies (see Section 3.2.1 for details). Overall, the available human evidence on PFHxS effects on the thyroid was considered indeterminate, and thus these studies were not considered for use in deriving toxicity values.

The database of animal studies examining PFHxS-induced thyroid effects includes one short-term study in rats (NTP, 2018a; Chang et al., 2018)and four multigenerational reproductive studies in rats and mice (three studies, four publications: (Ramhøj et al., 2018; Ramhøj et al., 2020; Chang et al., 2018; Butenhoff et al., 2009).Of these, a study in Crd:CD mice (Chang et al., 2018) was judged as low confidence and thus was not considered for POD derivation, leaving three high confidence studies in SD rats (NTP, 2018a; Butenhoff et al., 2009) or Wistar rats (Ramhøj et al., 2018; Ramhøj et al., 2020).

NTP (2018a) examined effects on serum concentrations of total and free T4 in adult rats, while Ramhøj et al. (2018) evaluated effects of PFHxS on free T4 serum levels in exposed dams and their offspring (exposed during gestation and lactation) through PND 22. NTP (2018a) observed a statistically significant, dose-dependent decrease (p < 0.01) of free and total T4 levels starting at the lowest experimental dose (0.625 mg/kg-day) in male rats (up to 60% in free T4 and 78% decrease in total T4). In female rats, T4 levels were significantly decreased beginning at higher doses (12.5 mg/kg-day and above), with 38% decrease in free T4 and 33% decreases in total T4 at the highest dose (50 mg/kg-day) (p < 0.01). Ramhøj et al. (2018) reported similar findings to those reported by NTP (2018a) in Wistar rat dams, with statistically significant, dose-dependent decreases in serum-free T4 at 5 mg/kg-day and above in dams at PND 22 after exposure from GD 7 through PND 16 or 17 (Ramhøj et al., 2018). In addition, Ramhøj et al. (2018) also reported statistically significant (p < 0.001) decreases in free T4 in the F1 offspring born from these PFHxS-exposed dams, with free T4 decreases at ≥5.0 mg/kg-day at both the end of exposure, PND16 or 17 (26%–32% decrease), and when pups were euthanized at PND 22 (26%–71% decrease). Total T4 assay measurements are more reliable that those provided by the assays available to measure free T4 in rodents as these are insufficiently sensitive to measure the very small quantity of unbound (i.e., “free”) T4 in circulation and therefore less reliable than total T4 measurements (personal communication with Mary Gilbert, EPA, ORD). For this reason, total, but not free, T4 was moved forward for POD and candidate value derivation.

Two studies measured T3 in serum (Ramhøj et al., 2020; NTP, 2018a). NTP (2018a) observed a statistically significant and dose-dependent decrease (p < 0.05) in serum T3 levels in male, but not female, SD rats at ≥0.625 mg/kg-day (p < 0.01). Ramhøj et al. (2020) analyzed samples taken in Ramhøj et al. (2018) and observed a significant decrease in serum T3 in Wistar rat dams at the highest tested dose: 19% decrease at 25 mg/kg-day (p < 0.001) measured on PND 22 after exposure from GD 7 through postnatal day 16 or 17. Overall, for TH changes, findings for both T4 and T3 in nonpregnant adult females were relatively insensitive as compared with adult males and thus set aside from further consideration.

Butenhoff et al. (2009) reported increased incidences of hypertrophy/hyperplasia in the thyroid. In this 44-day exposure study, Butenhoff et al. (2009) observed increased incidences of hypertrophy (characterized as “minimal”) of thyroid follicular epithelial cells in adult male rats that were exposed to 0.3 mg/kg-day PFHxS and an increase in “moderate” hypertrophy at the 10 mg/kg-day PFHxS dose for up to 44 days. Hypertrophy was not observed in control animals. Decreased thyroid hormone levels are judged relevant to human health, given the many similarities in the production, regulation, and functioning of thyroid hormones between rodents and humans (Zoeller and Rovet, 2004; Vansell, 2022; Stagnaro-Green and Rovet, 2016; Rovet, 2005, 2014; Navarro et al., 2014; Morreale de Escobar et al., 2008; Hood et al., 1999a; Hood et al., 1999b; Hood and Klaassen, 2000; Dong et al., 2015; Cuevas et al., 2005; Berbel et al., 2010). In addition, rodents are known to be more sensitive to increases in thyroid follicular hypertrophy and hyperplasia than humans, and thus the observed changes in thyroid hormone levels (which are not known to suffer from this same limitation) were preferentially advanced over these histopathological changes for deriving points of departure and the increases in thyroid hypertrophy/hyperplasia were not considered further (see Table 5-1).

Table 5-1 Endpoints considered for dose-response modeling and derivation of points of departure for thyroid effects in animals

Endpoint | Study reference and confidence | Exposure route and duration | Test strain, species, and sex | POD derivation | Notes
Decreased Total T4 | NTP (2018a), high confidence | Gavage, 28 d | Rat/SD/Male | Yes | Dose-dependent effects were observed across sexes, but responses were much more sensitive in males, even after considering sex-dependent PK differences.
Decreased Total T4 | Ramhøj et al. (2018), high confidence | Exposure in utero and lactation GD 7−PND 16 or 17; measurements taken at PND 16/17 | Rat/ Wistar /F1 Combined^a^ | Yes | Dose-dependent effects in combined serum from (male plus female) offspring were consistent across timepoints. Responses in dams were much less sensitive.
Decreased Total T4 | Ramhøj et al. (2018), high confidence | Exposure in utero and lactation GD 7–PND 16/17 measurements taken at PND 22 | Rat/ Wistar /F1 Combined^a^ | Yes | Dose-dependent effects in combined serum from (male plus female) offspring were consistent across timepoints. Responses in dams were much less sensitive.
Decreased Total T4 | Ramhøj et al. (2018), high confidence | Gavage GD 7–PND 16; Free T4 measured at GD 15 | Rat/ Wistar /P0 Female | No | Dose-dependent effects in combined serum from (male plus female) offspring were consistent across timepoints. Responses in dams were much less sensitive.
Decreased Total T4 | Ramhøj et al. (2018), high confidence | Gavage GD 7–PND 16; Free T4 measured at PND 22 | Rat/ Wistar /P0 Female | No | Dose-dependent effects in combined serum from (male plus female) offspring were consistent across timepoints. Responses in dams were much less sensitive.
Decreased T3 | NTP (2018a), high confidence | Gavage, 28 d | Rat/SD/Male | Yes | Dose-dependent effects were only observed in male rats.
Decreased T3 | Ramhøj et al. (2020), high confidence | Gavage GD 7–PND 16/17; T3 measured at PND 22 | Rat/ Wistar /P0 Female | No | Decrease was only observed in exposed dams and F1 pups at the highest dose. Responses in dams were much less sensitive.
Decreased T3 | Ramhøj et al. (2020), high confidence | In utero and lactation GD 7–PND 16/17 measurements taken at PND 16/17 | Rat/ Wistar /F1 Combined^a^ | Yes | Decrease was only observed in exposed dams and F1 pups at the highest dose. Responses in dams were much less sensitive.
Thyroid histopathology | Butenhoff et al. (2009) | 44 d | Rat/SD/P0; Male | No | Concern for potential reduced human relevance as compared with TH measures.

a Ramhøj et al. (2018) reported as combined male and female fetal and juvenile rats; individual female pup data not reported.

TH = thyroid hormone.

##### Immune effects

Consistent findings of reduced antibody responses from human epidemiological studies provide moderate human evidence of immunosuppression with PFHxS exposure. This conclusion is based primarily on two medium confidence studies (reported in three publications) in children (Grandjean et al., 2012; Grandjean et al., 2017b; Grandjean et al., 2017a), supported by additional studies in children and adults (Stein et al., 2016b; Stein et al., 2016a; Kielsen et al., 2016; Granum et al., 2013). Although there may be some residual uncertainty regarding the potential for confounding by other PFAS, including PFOA and PFOS, the evidence overall supports a concern for immunosuppression in PFHxS-exposed humans.

The two medium confidence studies of antibody response following vaccination are birth cohorts of similar populations in the Faroe Islands (see Table 5-2) (Grandjean et al., 2012; Grandjean et al., 2017b; Grandjean et al., 2017a). Across these studies, PFHxS exposure was measured during gestation, and at 18 months and 5, 7, and 13 years, and measures of antibody levels were taken at 5, 7, and 13 years for both diphtheria and tetanus. Inverse associations, indicating immunosuppression, were generally observed between PFHxS exposure and antibody levels across different combinations of timing of exposure and outcome measures, and similar findings were reported for other long-chain PFAS. However, there are a minority of combinations for which positive associations (higher antibody levels with higher PFHxS exposure) were observed (not statistically significant). This heterogeneity in results does not have a clear biologic explanation and the relevant etiologic window of exposure for this outcome is not known, although Grandjean et al. (2017b) noted that associations were generally weaker for two early life windows of PFHxS when exposures were measured at 18 months (as compared with PFHxS exposures measured prenatally or in early infancy) antibodies were measured at age 5 years, and for PFHxS exposures measured at 5 years of age and antibodies measured at age 5 years. Still, given the inverse associations observed for most of the exposure-outcome combinations and the low risk of bias in these studies (sensitivity was the primary concern), they are considered appropriate candidates for POD derivation. In Budtz-Jørgensen and Grandjean (2018), the study authors performed benchmark dose modeling for a subset of the data presented in these papers, specifically antibody levels at age 7 and PFHxS concentrations at age 5, and antibody levels at age 5 (prebooster) and perinatal PFHxS concentrations. The authors selected these combinations due to the strong inverse associations and because they are reasonably representative of the study results across exposure/outcome combinations, so after review of the BMD methods, their exposure-response results were used to inform the benchmark dose analyses. EPA selected a different BMR in deriving the BMDs and BMDLs (see Appendix D, Section 1 for more details).

Table 5-2 Endpoints considered for dose-response modeling and derivation of points of departure for immune (decreased serum antibody) effects in humans

Study reference and confidence | Antibody type; measurement timing | POD derivation | Notes
Antibody concentrations for diphtheria and tetanus | Grandjean et al. (2012); Grandjean et al. (2017a);and Grandjean et al. (2017b); medium confidence | No | Effect was generally coherent with epidemiological evidence for other antibody effects. However, while these results contribute to understanding the hazard for PFHxS, the analytic models in these specific publications used log-transformed exposure and log-transformed outcome variables and such log-log models cannot be used for BMD calculations and thus PODs were not derived.
Budtz-Jørgensen and Grandjean (2018) using data from Grandjean et al. (2012); Grandjean et al. (2017b); (Grandjean et al., 2017a) medium confidence | Decreased serum anti-tetanus antibody concentration in children at age 7 yr and PFHxS measured at age 5 yr | Yes | Both vaccine antibody types and the two exposure and outcome measurement timing combinations were generally coherent with the broader epidemiological evidence for antibody effects. Results were based on analytic models using log-transformed outcome and untransformed exposure which were suitable for BMD calculations and POD derivations (see Appendix D1 for more details on BMD modeling results).
Budtz-Jørgensen and Grandjean (2018) using data from Grandjean et al. (2012); Grandjean et al. (2017b); (Grandjean et al., 2017a) medium confidence | Decreased serum anti-diphtheria antibody concentration in children at age 7 yr and PFHxS measured at age 5 yr | Yes
Budtz-Jørgensen and Grandjean (2018) using data from Grandjean et al. (2012); Grandjean et al. (2017b); (Grandjean et al., 2017a) medium confidence | Decreased serum anti-tetanus antibody concentration in children at age 5 yr and PFHxS measured perinatally | Yes
Budtz-Jørgensen and Grandjean (2018) using data from Grandjean et al. (2012); Grandjean et al. (2017b); (Grandjean et al., 2017a) medium confidence | Decreased serum anti-diphtheria antibody concentration in children at age 5 yr and PFHxS measured perinatally | Yes

##### Developmental effects

Although the human evidence on developmental effects was highly uncertain and ultimately judged as slight (see Section 3.2.3), the database includes several well-conducted medium and high confidence epidemiological studies reporting birth weight deficits of varying magnitude in male or female neonates or both. A meta-analysis of the available studies showed a small but statistically significant decrease in birth weight per each ln-unit increase in PFHxS exposure (see Section 3.2.3; and Appendix C). However, in contrast to previous meta-analyses for PFOS and PFOA (Dzierlenga et al. (2020) and Steenland et al. (2018)), differences in detected deficits based on sample timing were evident for early sampled studies as well as high and medium/high confidence studies combined. Notably large effects were seen for postpartum measures, but this stratum was based on considerably fewer studies. This suggests that studies based on postpartum samples may be most prone to potential bias from pregnancy hemodynamics, but the meta-analytical data are indicative of complex patterns of influence due to pregnancy hemodynamic that are not completely understood. Nevertheless, the apparent influence of pregnancy hemodynamics introduces considerable uncertainty in the interpretation of these associations of evidence of PFHxS-induced developmental effects and was a major contributing factor in the overall evidence integration judgment for this health effect (see Section 3.2.3). Despite these important concerns regarding sample timing, as noted above, derivation of a POD(s) for developmental outcomes was considered potentially informative to toxicity value derivation for thyroid or immune effects.

For developmental effects, 22 epidemiology studies evaluated associations between PFHxS exposure and fetal growth restriction, seven of which were considered high confidence. Three of these high confidence studies measured maternal blood levels of PFHxS in the first trimester (Sagiv et al., 2018; Manzano-Salgado et al., 2017a; Buck Louis et al., 2018). One study each sampled in the second (Shoaff et al., 2018) third trimester (Valvi et al., 2017), while two studies collected samples across multiple trimesters (Starling et al., 2017; Bach et al., 2016).

Five of the seven high confidence studies reported adverse associations between birth weight and PFHxS, with no evidence of adverse associations reported in Valvi et al. (2017) or Sagiv et al. (2018).

Thus, the five high confidence studies considered for illustrative use in dose-response analysis (see Table 5-3) were: Buck Louis et al. (2018); Shoaff et al. (2018), Starling et al. (2017), Manzano-Salgado et al. (2019), and Bach et al. (2016). These studies showed consistent results especially when re-expressed on the ln-unit scale for consistency (range: −12 to −22 g per each ln-unit PFHxS increase).

As previously described, while no toxicity value for developmental effects will be derived due to the high uncertainty of any such value as compared with values based on thyroid or immune effects, the PODs for developmental effects are still useful for the purposes delineated above in Section 5.1.

Table 5-3 Mean birth weight deficit studies considered for dose-response modeling and derivation of points of departure for developmental effects in humans

Study reference and confidence | Population-overall population, sex-specific and all births vs. term births only | PFHxS biomarker sample timing | POD derivation | Notes
Buck Louis et al. (2018); high confidence | Overall population; term births | Trimester 1 | Yes | Effect size was large in magnitude; study showed some association for other endpoints such as birth length deficits. Maternal samples were collected during trimester one (range: 10–13.9 wk) which should minimize the pregnancy hemodynamic impact.
Manzano-Salgado et al. (2019); high confidence | Overall population; all births | Trimester 1 | Yes | Results based on continuous exposure increases were moderate in magnitude and consistent with larger birth weight deficits based on categorical data; study showed some coherence across other endpoints such as postnatal growth and other fetal growth indices. Maternal samples were collected during trimester one (mean = 12.3 wk) which should minimize the pregnancy hemodynamic impact. Multi-PFAS models were developed.
Shoaff et al. (2018); high confidence | Overall population; term births | Trimester 2 | Yes | Effect size was moderate in magnitude; study showed some coherence across other endpoints such as postnatal growth. Although the mean reported sampling period was 18 wk, it was variable across study participants (range: 16–40 wk) which may make a subset of these data (i.e., those with later sampling) more prone to potential bias from pregnancy hemodynamic changes.
Starling et al. (2017); high confidence | Overall population; term births | Trimesters 2–3 | Yes | Effect size was moderate in magnitude. Multi-PFAS models were developed. Median of 27 gestational wk of sampling. Concerns regarding the influence of pregnancy hemodynamic changes are generally greater for any trimester three PFHxS measures, but authors statistically adjusted for sampling timing.
Bach et al. (2016); high confidence | Overall population; sex-specific; term births | Trimester 1–2 | Yes^a^ | Results based on continuous exposure increases were moderate in magnitude and consistent with larger deficits based on categorical data and across sexes; this study also showed some coherence across other endpoints such as head circumference. Maternal samples were largely collected during trimesters one and two (range: 9–20 wk; mode: 12 wk) which may minimize the pregnancy hemodynamic impact.
Valvi et al. (2017); high confidence | Sex-specific; all births | Trimester 3 | No | Study reported increased birth weight (i.e., no adverse effects).
Sagiv et al. (2018); high confidence | Sex-specific; term births | Trimester 1 | No | Study showed mixed results.

a Study reported sex-specific findings that boys have larger deficits compared with girls. The associations between exposure and birth weight were not consistent across quantiles of exposures in girls. Results based overall population were used for POD derivation since the general population was the target population.

##### Hepatic effects

Although the human evidence on hepatic effects was uncertain and judged as slight (see Section 3.2.3), the database includes several medium and high confidence epidemiological studies reporting increases in clinical markers of liver disease. A key source of uncertainty was the potential for confounding by other PFAS. Despite this uncertainty, a POD was derived for serum ALT in humans to compare with PODs derived for the other, better supported health effects. From amongst the eight (out of 10 total) medium confidence studies that reported a positive association with ALT in adults, the medium confidence study by Kim et al. (2023) was determined to be the preferred choice for deriving a POD for adverse liver effects. Kim et al. (2023) used directed acyclic graphs (DAGs) to select potential confounders and all models included age, sex, education level, household income, smoking status, BMI, heavy drinking, regular exercise. Further, this study had the most robust approach to analyzing mixture effects and PFHxS had a positive weight in the mixture model (though other PFNA, PFOA, and PFOS had stronger weights). Details of the modeling for estimating the POD for PFHxS are in Appendix D.1. Selected POD results based on the preferred hybrid approach with two cutoff values defining adversity (i.e., >30 IU/L of ALT for women and >42 IU/L of ALT for men) are shown in Table 5-5.

Table 5-4 Endpoints considered for dose-response modeling and derivation of points of departure for liver effects in humans

Endpoint | Study reference and confidence | Population | POD derivation | Notes
Increased serum ALT | Kim et al. (2023), medium | Adults, male and female | Yes | Study examined a sub-population of the Korean National Environmental Health Survey (KoNEHS) and reported significant percentage changes in ln-ALT for log_2_-unit increase in PFNA of 2.8% (95% CI: −1.2, 7.0) for men and 3.7% (95% CI: −0.2, 7.8) for women using multiple linear regression adjusted for age, sex, education, income, smoking, heavy drinking, exercise, and BMI. The regression coefficients β were calculated as 0.0276 (95% CI: −0.0121, 0.0677) per log_2_ (ng/mL) PFHxS for men and 0.0363 (95% CI: −0.0020, 0.0751) ln-ALT(U/L) per log_2_ (ng/mL) PFHxS for women.^38^

#### Estimation or Selection of Points of Departure (PODs)

##### Benchmark dose modeling

Consistent with EPA’s Benchmark Dose Technical Guidance Document (U.S. EPA, 2012), the BMD and 95% lower confidence limit on the BMD (BMDL) were estimated using a BMR to represent a minimal, biologically significant level of change. The BMD Technical Guidance (U.S. EPA, 2012) sets up a hierarchy by which benchmark responses (BMRs) are selected. The first and preferred approach uses a biological or toxicological basis to define what minimal level of response or change is biologically significant. In the absence of information regarding the level of change that is considered biologically significant, a BMR of 1 SD from the control mean for continuous data or a BMR of 10% extra risk for dichotomous data is used to estimate the BMD and BMDL. The BMRs selected for dose-response modeling of PFHxS-induced health effects are listed in Table 5-4 along with the rationale for their selection. Further details, including the modeling output and graphical results for the model selected for each endpoint, can be found in Appendix D. When dose-response modeling was not feasible, or adequate modeling results were not obtained, no-observed-adverse-effect level (NOAEL) or lowest observed adverse effect level (LOAEL) values were identified and used as the POD.

Table 5-5 Benchmark response levels selected for BMD modeling of PFHxS outcomes

Endpoint | BMR | Rationale
Thyroid effects
Decreased serum-total T4 | 1 standard deviation | No information is readily available that allows for determining a minimally biological significant response. The BMD Technical Guidance (U.S. EPA, 2012) recommends a BMR based on 1 SD for continuous endpoints when biological information is not sufficient to identify the BMR.
Decreased serum-total T3 | 1 standard deviation
Immune effects
Decreased antibody concentrations for diphtheria and tetanus in children | ½ standard deviation | No information is readily available that allows for determining a minimally biological significant response. The BMD Technical Guidance (U.S. EPA, 2012) recommends a BMR based on 1 SD for continuous endpoints when biological information is not sufficient to identify the BMR. Diphtheria and tetanus are serious and sometimes fatal infections. In addition, childhood represents a sensitive lifestage when immunosuppression during the developmental stage may impede children’s ability to protect against a range of immune hazards. Given the potential severity of this outcome, a BMR of ½ SD was selected (see additional discussion in Appendix D, Section 1.1).
Developmental effects
Decreased birth weight in humans | 5% extra risk of exceeding adversity cutoff (hybrid approach^a^) | A 5% extra risk is commonly used for dichotomous developmental endpoints as recommended by Benchmark Dose Technical Guidance (U.S. EPA, 2012). For birth weight, a public health definition of low birth weight exists, and the hybrid approach was used to estimate the dose at which the extra risk of falling below that cutoff equaled 5% (see Appendix D).
Hepatic effects
Increased serum ALT in humans | 10% extra risk exceeding adversity cutoff (hybrid approach^a^) | Both extra risks of 5% and 10% were considered. A BMR of less than 10% can be supported for severe or debilitating health outcomes. Given the findings of associations between increased ALT and severe liver disease (Park et al., 2019), a BMR of 5% was considered. However, modest elevations in ALT are more likely associated with milder forms of liver injury, including steatosis and NAFLD (Oh et al., 2017). Because of uncertainties in measuring ALT, in selecting the most appropriate upper limit of normal (and the difficulty in interpreting specific elevations above the upper limit of normal as adverse), and in selecting the reference population, a BMR of 10% extra risk was selected as a “minimally adverse” effect and as a standard reporting level per EPA’s Benchmark Dose Technical Guidance (U.S. EPA, 2012). See also Appendix D Section D.1.2.

a The hybrid approach to defining the continuous BMR retains the full power of modeling continuous data (i.e., retains information on the distribution of continuous responses instead of dichotomizing the response variable) and incorporates biological, toxicological, or clinical knowledge in setting the adversity cutoff (U.S. EPA, 2012, 2023a)

When modeling was feasible, the estimated BMDLs were used as PODs (see Table 5-6). Further details, including the modeling output and graphical results for the model selected for each endpoint, can be found in Appendix D. For the modeling of immune effects, potential confounding by other PFOS and PFOA was considered in the POD derivation by comparing the effect estimates from the analyses in and BMDLs for PFHxS from single-PFAS models against those from multi-PFAS models controlling for PFOS and PFOA in analyses by Budtz-Jørgensen and Grandjean (2018) (see Appendix D, Section 1 for details). When dose-response modeling was not feasible, or adequate modeling results were not obtained, NOAEL or LOAEL values were identified based on biological rationales when possible and used as the POD. The PODs (based on BMD modeling or NOAEL/LOAEL selection) for the endpoints advanced for dose-response analysis are presented in Table 5-6 alongside the corresponding POD_HED_s derived based on the PK extrapolations as described in Section 3.1.6.

Table 5-6 Points of departure (PODs) considered for the derivation of PFHxS candidate toxicity values

Endpoint | Study/confidence | Species/sex | POD type (% change if NOAEL or LOAEL) | Free acid POD (mg/kg-d)^f^ | [underlined: POD_internal_] internal dose (mg/L) or DDEF (no units)^c^ | Free acid POD_HED_^d^ (mg/kg-d)
Thyroid
Decreased Total T4 | 28-d study; NTP (2018a), high confidence | SD rat, male | LOAEL^a^ (−44%) | 0.684 | [underlined: POD_internal_]: 34.58 | 1.42 × 10^−3^
Decreased Total T4 | Multigenerational Study; Ramhøj et al. (2018), high confidence | Wistar rat, Combined F_1_ (PND 16/17) | NOAEL^b^ (+4%) | 0.051 | 4.81 × 10^−4^ | 2.45 × 10^−5^
Decreased T3 | Multigenerational Study; Ramhøj et al. (2020), high confidence | Wistar rat, Combined F_1_ (PND 16/17) | NOAEL^b^ (−7%) | 5.5 | 4.81 × 10^−4^ | 2.65 × 10^−3^
Decreased T3 | 28-d study; NTP (2018a), high confidence | SD rat, male | LOAEL^a^ (−22%) | 0.684 | [underlined: POD_internal_]: 34.58 (mg/L) | 1.42 × 10^−3^
Immune (developmental)
Decreased serum anti-tetanus antibody concentration in children at age 7 and PFHxS conc measured at age 5 | Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018), medium confidence | Human (children)/both | BMDL_½ SD_ | –^e^ | 2.82 × 10^−4^ | 1.16 × 10^−8^
Decreased serum anti-diphtheria antibody concentration in children at age 7 and PFHxS conc measured at age 5 | Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018), medium confidence | Human (children)/both | BMDL_½ SD_ | –^e^ | 3.00 × 10^−4^ | 1.23 × 10^−8^
Decreased serum anti-tetanus antibody concentration in children at age 5 and PFHxS conc measured perinatally | Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018), medium confidence | Human (children)/both | BMDL_½ SD_ | –^e^ | 1.44 × 10^−2^ | 5.90 × 10^−7^
Decreased serum anti-diphtheria antibody concentration in children at age 5 and PFHxS conc measured perinatally | Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018), medium confidence | Human (children)/both | BMDL_½ SD_ | –^e^ | 1.37 × 10^−2^ | 5.62 × 10^−7^
Developmental^g^
Decreased birth weight | Bach et al. (2016), high confidence | Human (newborn)/Both | BMDL_5ER_, Hybrid | –^e^ | 1.12 × 10^−3^ | 8.06 × 10^−8^
Decreased birth weight | Buck Louis et al. (2018), high confidence | Human (newborn)/Both | BMDL_5ER_, Hybrid | –^e^ | 1.71 × 10^−3^ | 1.23 × 10^−7^
Decreased birth weight | Manzano-Salgado et al. (2019), high confidence | Human (newborn)/Both | BMDL_5ER_, Hybrid | –^e^ | 1.33 × 10^−3^ | 9.58 × 10^−8^
Hepatic
Increased ALT representing increased risk of liver effects^h^ | Kim et al. (2023), Medium Confidence | Human, female | BMDL_ER5,_ Hybrid with cutoff of 30 IU/L of ALT for women | –^e^ | 2.22 × 10^−3^ | 9.10 × 10^−8^
Increased ALT representing increased risk of liver effects^h^ | Kim et al. (2023), Medium Confidence | Human, female | BMDL_ER10,_ Hybrid with cutoff of 30 IU/L of ALT for women | –^e^ | 4 .18 × 10^−3^ | 1.71 × 10^−7^
Increased ALT representing increased risk of liver effects^h^ | Kim et al. (2023), Medium Confidence | Human, male | BMDL_ER5,_ Hybrid with cutoff of 42 IU/L of ALT for men | –^e^ | 3.14 × 10^−3^ | 1.29 × 10^−7^
Increased ALT representing increased risk of liver effects^h^ | Kim et al. (2023), Medium Confidence | Human, male | BMDL_ER10,_ Hybrid with cutoff of 42 IU/L of ALT for men | –^e^ | 6.58 × 10^−3^ | 2.70 × 10^−7^

a No models provided adequate fit; therefore, a freestanding LOAEL, no NOAEL was identified as there were statistically significant effects in the lowest dose.

b No models provided adequate fit; therefore, NOAEL approach was used.

c For thyroid effects in male rats from the NTP bioassay, the internal dose, POD_internal_, was calculated by interpolation of the measured end-of-study concentrations in the rats, as described in Section 3.1.7, and POD_HED =_ POD × CL_H_, where CL_H_ is the estimated human clearance for the general population from Table 3-5. For thyroid effects from the multigenerational study of Ramhøj et al. (2018), POD_HED =_ POD × DDEF, where the DDEF corresponding to the rat sex for the observation is taken from Table 3-7; the lower DDEF for female rats used for observations in combined sex groups.

d For immune and developmental effects observed at PND 16/17 in rats or associated with serum concentrations measured in children at age 5 POD_HED_ was calculated assuming steady-state serum concentrations using CL for human males and older women, since the endpoint is assumed to depend on serum concentrations in the offspring, for which the lower clearance (not including the factor for menstrual-associated clearance) is relevant. For effects observed at birth or associated with perinatal maternal serum concentrations, CL for humans included the factor for menstrual-associated clearance, since maternal serum concentrations throughout pregnancy are similar to or below prepregnancy concentrations, which result from the total clearance of the reproductive age woman.

e BMD modeling was done on serum concentrations and hence there was no POD based on external dose.

f POD for PFHxS free acid were calculated by taking the LOAEL or NOAEL and multiplying by the ratio of potassium salt/ molecular weight of the free acid.

g Although PODs were derived for five birth weight studies (see above), there was less uncertainty in three developmental epidemiological studies noted here with earlier maternal biomarker sampling (Manzano-Salgado et al., 2019; Buck Louis et al., 2018; Bach et al., 2016).

h Cutoffs for adversity based on ALT concentrations of 30 IU/L for women and 42 IU/L for men are discussed in Appendix D.1.

#### Derivation of Candidate Lifetime Toxicity Values for the Reference Dose (RfD)

As discussed, below the developmental period is recognized as a susceptible lifestage when exposure during a critical time window is more relevant to the induction of adverse effects than lifetime exposure. Thus, the derivation of a lifetime value for developmental thyroid and immune endpoints following PFHxS exposure is supported. Exposure during pregnancy was also considered a potentially susceptible lifestage. Consistent with EPA guidelines (U.S. EPA, 1994), the thyroid hormone PODs following 28-day PFHxS exposure in adult SD rats were not considered for derivation of candidate lifetime values given the high degree of uncertainty associated with using PODs from a 28-day rodent study to protect against effects observed in a chronic setting. However, these endpoints were considered for the derivation of the subchronic RfD (see Section 5.2.2). Overall, the developmental immune endpoints from epidemiological studies and thyroid endpoints, specifically decreases in T3 and total T4, from a multigenerational rodent study of PFHxS, were preferentially advanced for the derivation of candidate lifetime values.

For developmental immune effects, the POD_Internal_ was 0.282 ng/mL (see Appendix D.1). Grandjean and Bateson (2021) provides the minimum measured PFHxS concentration (0.02 ng/mL), the 5^th^% (0.2 ng/mL) and the 10^th^% (0.3 ng/mL) so the BMDL is between the 5^th^ and 10^th^% of the observed measurements. The estimated limit of detection of PFHxS was 0.007 ng/mL and the limit of quantification was 0.02 ng/mL in serum (Haug et al., 2009). POD_HED_ values were derived for decreased serum antibody levels (for both diphtheria and tetanus) in children (male and female) at different timing of exposure and outcome measurement combinations, specifically antibody levels at age 7 and PFHxS concentrations at age 5, and antibody levels at age 5 and perinatal PFHxS concentrations (Budtz-Jørgensen and Grandjean, 2018) (see Table 5-5). The BMDL_½SD(HED)_ of 1.16 × 10^−8^ mg/kg-day for decreased serum anti-tetanus antibody concentrations at age 7 and PFHxS measured at age 5 is selected for the derivation of osRfDs for immune effects. Confidence in the BMDL estimate was highest (medium confidence) for this endpoint in comparison with other exposure-outcome combinations evaluated by Grandjean et al. (2012) and Budtz-Jørgensen and Grandjean (2018) based on a better fit model for PFHxS in the single-PFAS model and less uncertainty with respect to potential confounding with other co-occurring PFAS (i.e., PFOS and PFOA) (see Appendix D, Section1.1 for more details). The BMDL_½SD(HED)_ of 1.23 × 10^−8^ mg/kg-day for decreased serum anti-diphtheria antibody concentrations at age 7 and PFHxS measured at age 5 is also selected for the derivation of osRfDs for immune effects. Confidence in this BMDL estimate was somewhat lower (medium/low confidence) for this endpoint than for anti-tetanus antibody concentrations at age 7 (see Appendix D, Section1.1 for more details). Further, although both tetanus and diphtheria are rare in the United States, tetanus remains more of a concern primarily among older adults, who are unvaccinated or inadequately vaccinated and therefore are at higher risk of disease and mortality (Liang et al., 2018). The estimated BMDL_½SD_ (2.82 × 10^−4^ mg/L) for this endpoint in the single-PFAS model is at about the 10th percentile of the observed distribution. No information was available to judge the fit of the model in the range of the BMDLs, but the BMD and BMDL were both within the range of observed values and the model fit PFHxS well (see Appendix D, Section 1.1 for more details). The fact that the derived POD_HED_ for immune effects on both tetanus and diphtheria antibody concentrations at the same ages are relatively close (1.16 × 10^−8^ mg/kg-day versus 1.23 × 10^−8^ mg/kg-day) lends support to the choice of the POD_HED_ of 1.16 × 10^−8^ mg/kg-day for decreased serum anti-tetanus antibody concentrations at age 7 and PFHxS measured at age 5 for the derivation of the osRfD.

For thyroid osRfD, POD_HED_ values were derived for decreased total thyroxine (T4) as well as decreased triiodothyronine (T3) in a multigenerational reproductive study, with exposure including all of gestation (Ramhøj et al., 2018; Ramhøj et al., 2020) and a 28-day comprehensive toxicity study in rats (NTP, 2018a) (see Table 5-6). The POD_HED_ of 2.14 × 10^−5^ for decreased total T4 in combined F_1_ Wistar rats is selected for the derivation of osRfD for thyroid effects as it was the most sensitive and reliable measure of thyroid hormone function (see Table 5-6). As described previously, although candidate toxicity values were not derived for developmental or hepatic effects (decreased birth weight and increased ALT, respectively), PODs for these outcomes were derived as they were considered informative of the magnitude of effects relevant to susceptible lifestages and populations and may help inform uncertainty factor selection for developmental immune effects and thyroid effects. The lowest PODs derived for developmental and hepatic effects are 7- and 8-fold higher than the lowest POD derived for developmental immune effects. Thus, derivation of an RfD based on the developmental immune effects would be protective of developmental (decreased birth weight) and hepatic (increased ALT) effects.

Under EPA’s A Review of the Reference Dose and Reference Concentration Processes (U.S. EPA, 2002) and Methods for Derivation of Inhalation Reference Concentrations and Application of Inhalation Dosimetry (U.S. EPA, 1994), five possible areas of uncertainty and variability were considered in deriving the candidate values for PFHxS. An explanation of these five possible areas of uncertainty and variability and the values assigned to each as a designated uncertainty factor (UF) to be applied to the candidate POD_HED_ values are listed in Table 5-7, below.

Table 5-7 Uncertainty factors for the development of the lifetime RfD for PFHxS

| Value | Justification
UF_A_ | 1 | A UF_A_ of 1 is applied to the POD derived from developmental immune effects as these responses were observed in epidemiological studies.
UF_A_ | 3 | For thyroid effects, a UF_A_ of 3 is applied to account for uncertainty in characterizing the pharmacokinetic and pharmacodynamic differences between mice or rats and humans following oral PFHxS exposure. Some aspects of the cross-species extrapolation of pharmacokinetic processes have been accounted for using a DDEF to convert external doses from rodents to administered doses in humans; however, residual uncertainty related to potential pharmacodynamic differences remains.
UF_H_ | 10 | A UF_H_ of 10 is applied for developmental immune and thyroid effects. This is to account for interindividual variability in humans in the absence of quantitative information on potential differences in pharmacokinetics and pharmacodynamics relating to PFHxS exposure in humans. (See discussion below for additional details).
UF_S_ | 1 | A UF_S_ of 1 is applied to reduced antibody responses in children (Grandjean et al., 2012; Budtz-Jørgensen and Grandjean, 2018). The developmental period is recognized as a susceptible lifestage when exposure during a critical window of development is more relevant than lifetime exposure in adulthood (U.S. EPA, 1991). Additional considerations for the UF_s_ for immune effects are discussed below.
UF_S_ | 1 | A UF_S_ of 1 is applied to thyroid effects observed in the F1 animals from reproductive study (Ramhøj et al., 2018); the developmental period is a susceptible lifestage where exposure during certain time windows (e.g., pregnancy and gestation) is more relevant to the induction of developmental effects than lifetime exposure (U.S. EPA, 1991).
UF_L_ | 1 | A UF_L_ of 1 is applied for LOAEL-to-NOAEL extrapolation when the POD is a BMDL as is the case for developmental immune endpoint or POD is a NOAEL as is the case for the thyroid endpoint.
UF_D_ | 3 | A UFD of 3 is applied to account for deficiencies and uncertainties in the database. Although limited, the evidence base in laboratory animals consists of high/medium confidence short-term studies in rodents and a high confidence developmental study in mice. The database for PFHxS also includes several high/medium confidence epidemiological studies most informative for immune and developmental effects, which are sensitive effects of PFHxS exposure. However, uncertainties remain regarding the lack of studies examining effects with long-term exposure in adults—including in women of reproductive age (which may have increased susceptibility), studies of potential multigenerational effects, and studies of postnatal development, neurotoxicity, and thyroid toxicity during developmental lifestages. In all, the data are too sparse to conclude with certainty that the quantified developmental effects are likely to be the most sensitive; thus, a UFD of 1 was not selected. However, a UFD of 10 was also not selected given the availability of data from well-conducted studies on a range of health outcomes in multiple species, including sensitive evaluations of developmental and immune endpoints in humans. See discussion below for additional details.
UF_C_ | See Table 5-8 | Composite Uncertainty Factor = UF_A_ × UF_H_ × UF_S_ × UF_L_ × UF_D_

As described in EPA’s A Review of the Reference Dose and Reference Concentration Processes (U.S. EPA, 2002), the interspecies uncertainty factor (UF_A_) is applied to account for extrapolation of animal data to humans, and accounts for uncertainty regarding the pharmacokinetic and pharmacodynamic differences across species. As is usual in the application of this uncertainty factor, the pharmacokinetic uncertainty is mostly accounted for through the application of dosimetric approaches for estimation of HEDs. This leaves some residual uncertainty around the pharmacokinetics and the uncertainty surrounding pharmacodynamics. For developmental immune effects, a UF_A_ = 1 was applied to the POD as these responses were observed in epidemiological studies. For thyroid effects, a UF_A_ = 3 was applied to the POD derived from rodent studies to account for interspecies uncertainty. While uncertainty in the pharmacokinetic processes has largely been accounted for by using a DDEF to convert external rodent doses to human administered doses, a UF_A_ = 3 was applied to address the remaining pharmacokinetic uncertainty and to address the pharmacodynamic uncertainty in extrapolating those effects to humans (see Uncertainty in HED Calculations for more details.).

For developmental immune effects in children, a UF_H_ of either 3 or 10 was considered. Specifically, it can be argued that the PODs are derived from susceptible individuals because children’s immune systems are not fully formed and are presumably more sensitive to these effects than most other populations, and thus, the UF_H_ should be reduced (although uncertainty regarding differences across individuals exposed during this sensitive lifestage would still remain). However, a counter argument is that currently there are no data to compare the responses in children with other populations or lifestages, so it is unclear whether these individuals are indeed particularly susceptible to these specific effects. As described in U.S. EPA (2020), other factors, in addition to lifestage, may increase susceptibility, including: demographics, genetic variability, health status, behavior or practices, and social determinants. Ultimately, because the current evidence is insufficient to address these uncertainties, a UF_H_ of 10 is applied for developmental immune effects. For thyroid effects, a UF_H_ of 10 is applied to address differences due to intraspecies variability, including potentially more sensitive or severe effects in susceptible populations or lifestages.

The duration extrapolation factor (UF_s_) accounts for the uncertainty in extrapolating from less than chronic PFHxS exposure to lifetime exposure. A UF_s_ = 1 was applied to the PODs for thyroid effects as the selected POD was derived from a reproductive study with exposure encompassing the critical window of gestation (Ramhøj et al., 2018). This developmental window is recognized as a susceptible lifestage when exposure is more relevant to the induction of developmental effects than lifetime exposure (U.S. EPA, 1991). The reduced antibody responses were measured in children 5–7 years of age, which also constitutes a sensitive lifestage. However, given the slow clearance rates for this chemical, particularly in humans (see Table 3-5), PFHxS is expected to accumulate in the body through adulthood. Therefore, it is plausible that longer exposure durations can result in effects at lower exposure levels. Although the MOA for PFHxS-induced immunosuppressive responses in humans is unknown, early-life exposures may alter the immune system and lead to unpredictable outcomes later in life or during other susceptible lifestages of reduced immunocompetence such as pregnancy, advanced lifestages, or immunocompromised states (IPCS, 2012) that show increased sensitivity with continuous, longer-term exposures. Still, given the expectation that the children and their mothers have been exposed to elevated levels of PFHxS for many years, the observed effects on immune response are considered the result of a cumulative, prolonged PFHxS exposure to the subjects from conception until the age when the response was evaluated. Further, the consequences of perturbed immune system function (in this case, suppressed antibody responses leading to potentially increased risk of disease) during development are expected to be generally more severe and longer lasting that those that manifest in healthy adults. Thus, a UF_s_ of 1 was considered appropriate.

The database uncertainty factor (UF_D_) is applied to account for the potential of deriving an under-protective reference value as a result of incomplete characterization of a chemical’s toxicity (U.S. EPA, 2002). For PFHxS, a UF_D_ of 3 was selected to account for deficiencies and uncertainties in the database. Although limited, the evidence base in laboratory animals consists of high/medium confidence short-term studies in rodents and a high confidence developmental study in mice. The database for PFHxS also includes several high/medium confidence epidemiological studies most informative for immune and developmental effects, which are sensitive effects of PFHxS exposure. However, uncertainties remain regarding the lack of studies examining effects with long-term exposure in adults—including in women of reproductive age (which may have increased susceptibility), studies of potential multigenerational effects, and studies of postnatal development, neurotoxicity, and thyroid toxicity during developmental lifestages. Typically, the specific study types lacking in a chemical’s database that influence the value of the UF_D_ to the greatest degree are developmental toxicity and multigenerational reproductive toxicity studies. While the PFHxS database does include high confidence reproductive/developmental toxicity studies in rats and mice, these only span one-generation. Therefore, despite their quality, these studies fail to cover potential transgenerational impacts of longer-term exposures evaluated in two-generation studies. The availability of a two-generation multigenerational reproductive study could result in reference values below those currently derived for PFHxS. However, the concern over a lack of two-generation study in the available literature is diminished when the PFHxS, PFDA, PFOA, and PFOS evidence bases are considered together. Although limited in their ability to assess reproductive health or function, measures of possible reproductive toxicity occurred at doses equal to or higher than those that resulted in effects in other organ systems (e.g., thyroid, liver) when measured after exposure to PFHxS in utero through PND 22 (Ramhøj et al., 2018). Similar results were observed for the animal databases for PFOA and PFOS indicating reproductive effects were not uniquely sensitive markers of toxicity for these long-chain PFAS (ATSDR, 2021). Further, no notable male or female reproductive effects were observed in epidemiological or toxicological studies investigating exposure to PFHxS (MDH, 2019). Given these overall uncertainties with the database, a threefold UF was applied.

The uncertainty factors described in Table 5-7 and the text above were applied and the resulting candidate values are shown in Table 5-8. The candidate values are derived by dividing the POD_HED_ by the composite uncertainty factor:

Candidate values for PFHxS = P O D_H E D_ ÷ U F_C_ . (3-5)

Table 5-8 Lifetime candidate values for PFHxS

Endpoint | Study/confidence | Strain/species/sex | Free acid POD_HED_ (mg/kg-d) | UF_A_ | UF_H_ | UF_S_ | UF_L_ | UF_D_ | UF_C_ | Candidate value (mg/kg-d)
Thyroid
Decreased Total T4 | Ramhøj et al. (2018), high confidence; Wistar rat, combined F1 | Wistar rat, Combined F_1_ (PND 16/17) | 2.45 × 10^−5^ | 3 | 10 | 1 | 1 | 3 | 100 | 2 × 10^−7^
Decreased T3 | Multigenerational Study; Ramhøj et al. (2020), high confidence | Wistar rat, Combined F_1_ (PND 16/17) | 2.65 × 10^−3^ | 3 | 10 | 1 | 1 | 3 | 100 | 3 × 10^−5^
Developmental immune effects
Decreased serum anti-tetanus antibody concentration in children at age 7 | Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018); medium confidence | Human (children), male and female | 1.16 × 10^−8^ | 1 | 10 | 1 | 1 | 3 | 30 | 4 × 10^−10^
Decreased serum anti-diphtheria antibody concentration in children at age 7 | Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018); medium confidence | Human (children), male and female | 1.23 × 10^−8^ | 1 | 10 | 1 | 1 | 3 | 30 | 4 × 10^−10^

#### Selection of Lifetime Toxicity Value(s)

##### Selection of organ-/system-specific oral reference doses (osRfDs)

Table 5-8 shows osRfDs selected for the individual organ systems identified in Section 3.2 (i.e., thyroid and developmental immune effects).

The value of 4 × 10^−10^ mg/kg-day (rounded from 3.9 × 10^−10^ and, separately, 4.1 × 10^−10^ mg/kg-day in Table 5-8 for decreased serum anti-tetanus and anti-diphtheria antibody concentrations in children (male and female) at age 7 years and PFHxS measured at age 5 years from the Grandjean et al. (2012) and Budtz-Jørgensen and Grandjean (2018) was selected as the osRfD for developmental immune effects. The respective POD_HED_ values for these two endpoints (decreased anti-tetanus as well as decreased anti-diphtheria antibodies) were close in value (1.16 × 10^−8^ versus 1.23 × 10^−8^, respectively) and the candidate values round to the same toxicity value.

For the thyroid effects, an osRfD of 2 × 10^−7^ mg/kg-day (rounded from 2.45 × 10^−7^ in Table 5-8) was selected based on decreased total T4 in F1 pups exposed to PFHxS in the Ramhøj et al. (2018). As there was no other reason to select one POD over the other (e.g., different levels of confidence in the POD calculations), the more sensitive POD for total T4 was selected over the POD for T3.

The confidence decisions about the study, evidence base, quantification of the POD, and overall RfD for these organ-/system-specific values are described in detail in Table 5-9, along with the rationales for selection of confidence levels. In deciding overall confidence, confidence in the evidence base is prioritized over the other confidence decisions. The overall confidence in the osRfDs for both immune and thyroid effects is judged as medium. Selection of the overall RfD is described in the following section.

Table 5-9 Confidence in the organ-/system-specific RfDs for PFHxS

Confidence categories | Designation | Discussion
Thyroid 2 × 10^−7^ RfD = mg/kg-d
Confidence in study^a^ used to derive osRfD | High | Confidence in Ramhøj et al. (2018) was high and is based on a well-designed experimental design using established approaches, recommendations, and best practices (HAWC link (https://hawc.epa.gov/rob/study/100518066/)).
Confidence in evidence base supporting this hazard | Medium | Confidence in the evidence base for thyroid effects is medium based on consistent findings in animals of decreases in T3 and T4 in adult and juvenile rats in the absence of effects on TSH (Ramhøj et al., 2018; NTP, 2018a), but with unexplained inconsistency in the available epidemiological studies and other uncertainties (see Table 3-8).
Confidence in quantification of the POD_HED_ | Medium | Confidence in the quantification of the POD_HED_ and osRfD is medium given POD was based on a NOAEL (data did not fit BMD models) and because a DDEF was applied to estimate the POD_HED_. The uncertainty associated with the use of a DDEF is less than the uncertainty introduced from the use of a NOAEL because the DDEF is based on PFHxS-specific pharmacokinetic data (see Uncertainty in HED Calculations). Considering these limitations, confidence in the POD was medium.
Overall confidence in osRfD | Medium | The overall confidence in the osRfD is medium. The medium confidence in the POD derivation is offset by the high confidence in the study and medium confidence in the evidence base for thyroid effects.
Developmental Immune RfD = 4 × 10^−10^
Confidence in study^a^ used to derive osRfD | Medium | Confidence in Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018) was rated as medium based on some concerns for sensitivity from narrow exposure contrast, which decreases confidence in null associations only (HAWC link (https://hawc.epa.gov/rob/study/100517986/)).
Confidence in evidence base supporting this hazard | Medium | Confidence in the evidence base for immune effects is medium based on consistent findings of reduced antibody responses from two medium confidence birth cohort studies (Grandjean et al., 2012; Grandjean et al., 2017b; Grandjean et al., 2017a) and a low confidence study in adults (Grandjean et al., 2017b). Limitations in this evidence base include the lack of epidemiological studies in adults or long-term/chronic studies in animals, and a general lack of studies examining effects on the immune system across different developmental immunotoxicity categories, including sensitization and allergic response and autoimmunity and autoimmune disease.
Confidence in quantification of the POD_HED_ | Medium | The POD is based on BMD modeling within the range of the observed data and a BMDL_½SD_ estimate that is associated with little uncertainty due to potential confounding by PFOA or PFOS (see Appendix D, Section 1.1 for more details). The POD_HED_s for decreased anti-tetanus and decreased anti-diphtheria antibodies were close in value (1.16 × 10^−8^ vs. 1.23 × 10^−8^, respectively) which increases confidence in the quantification of the POD_HED_. There is uncertainty as to the most sensitive window of vulnerability with respect to the exposure/outcome measurement timing (BMDs/BMDLs were estimated from PFHxS levels measured at age 5 or perinatally and anti-tetanus antibody concentrations measured at age 7 or 5) and the effect on antibodies at age 7 were more sensitive that those measured at age 5 (see Appendix D, Section 1.1 for more details); however, Grandjean et al. (2017b) reported that estimated PFOS and PFOA “concentrations at 3 m and 6 m showed the strongest inverse associations with antibody concentrations at age 5 yr, particularly for tetanus.” Thus, it is possible that adverse effects of PFHxS during infancy could be more sensitive than between ages 5 and 7 yr.
Overall confidence in osRfD | Medium | The overall confidence in the osRfD is medium and is driven by medium confidence in the evidence base for immune effects, the quantification of the POD, and the study used for BMD modeling.

a All study evaluation details can be found on HAWC.

##### Selection of overall reference dose (RfD) and confidence statement

Table 5-10 RfD and organ-/system-specific RfDs for PFHxS

Reference dose (RfD)
Basis | RfD (mg/kg-d) | | Confidence
Immune (developmental) effects | 4 × 10^−10^ | | Medium
Organ-/system-specific RfDs (osRfDs)
Organ/system | Outcomes and studies | POD_HED_ (mg/kg-d) | UFC | osRfD (mg/kg-d)^a^ | Confidence
Thyroid | Decreased serum-total T4 in F1 Wistar rats; (Ramhøj et al., 2018) | 2.45 × 10^−5^ | 100 | 2 × 10^−7^ | Medium
Immune (developmental) | Decreased serum anti-tetanus and anti-diphtheria antibody concentrations measured in children at age 7 with PFHxS exposure measured at age 5; Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018); Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018) | 1.16 × 10^−9^ and 1.23 × 10^−9^ | 30 | 4 × 10^−10^ | Medium

a The RfD or osRfD values for different salts of PFHxS would be calculated by multiplying the RfD or osRfD values for the free acid of PFHxS (i.e.,, the toxicity values in the table above) by the ratio of molecular weights. For example, for the potassium salt the ratio would be: (M W a p o t a s s i u m s a l t)/(M W f r e e a c i d) = (438)/(400) = 1.095 . This same method of conversion can be applied to other salts of PFHxS, such as the ammonium or sodium salts, using the corresponding molecular weights.

From the identified human health effects of PFHxS and derived osRfDs for thyroid and developmental immune effects (see Table 5-10), an RfD of 4 × 10^−10^ mg/kg-day was selected based on decreased serum anti-tetanus and anti-diphtheria antibody concentrations in children. As described in Table 5-9, confidence in the RfD is medium, based on medium confidence in the developmental immune osRfD. This osRfD is based on the two lowest POD_HED_s available on PFHxS immune effects (an evidence based interpreted with medium confidence) using a study considered medium confidence. The selected osRfD is based on effects in children and expected to be protective across all lifestages. The selection considered both available osRfDs as well as the overall confidence and composite uncertainty for those osRfDs. The thyroid osRfD was based on application of a composite uncertainty threefold greater than that applied in deriving the immune osRfD. Further, when comparing the sensitivity of thyroid and immune osRfDs, the thyroid value is over 3,000-fold higher. Had the osRfD for thyroid effects been chosen as the overall RfD, this would have raised concerns over the ability of the thyroid RfD to be protective against potential immune effects (and it may not be protective against other developmental effects, such as decreased birth weight (see Table 5-7) if those other effects could be reliably quantified). Selection of the RfD on the basis of developmental immune effects is presumed to be protective of possible thyroid and other potential adverse health effects (including potential effects on birth weight and hepatotoxicity [increased ALT levels]) in humans. Finally, because the developmental immune osRfD is based on effects observed in males and females, the overall RfD would be protective for both sexes.

### 5.2.2 Subchronic Toxicity Values for Oral Exposure (Subchronic Oral Reference Dose [RfD]) Derivation

In addition to providing an RfD for lifetime exposure in health systems, this document also provides an RfD for less-than-lifetime (“subchronic”) exposures. These candidate subchronic toxicity values were based on the endpoints and PODs in Table 5-6 including the shorter duration studies that were not advanced for consideration in developing the lifetime RfD. Given that the immune and thyroid effects considered for the RfD were observed after exposure to PFHxS during susceptible lifestages, these endpoints were also considered for the derivation of candidate subchronic toxicity values, applying identical uncertainty factors to those used for the lifetime RfDs (see Table 5-7).

The datasets advanced for derivation of the subchronic toxicity values were selected on the basis of several considerations, including whether there is an endpoint with less uncertainty and/or greater sensitivity, and whether the endpoint is protective of both sexes and all lifestages. Ultimately, similar to the datasets advanced for the lifetime thyroid osRfD derivation, decreased total T4 and decreased T3 endpoints from the Ramhøj et al. (2018) study was advanced over identical endpoints from the high confidence NTP (2018a) study. This is because the Ramhøj et al. (2018) study included exposure to PFHxS during gestation, this exposure is interpreted as a critical sensitive window for effects on the developing thyroid system. Further, consistent with the decision when estimating the lifetime osRfD, the POD for total T4 was advanced over the POD for T3 from Ramhøj et al. (2018) given the increased sensitivity of the POD. The NOAEL_HED_ of 1.92 × 10^−5^ mg/kg-day for decreased total T4 in F1 generation rats in the Ramhøj et al. (2018) study was selected for the thyroid subchronic osRfD (see Table 5-6). The UFs applied to the derivation of a subchronic RfD thyroid POD in rat offspring are the same as those applied in the derivation of lifetime RfD values. See Table 5-7 for details.

Likewise, the same datasets on developmental immune effects were advanced for derivation of the subchronic osRfD, with the same inherent confidence and uncertainties.

#### Selection of Subchronic Toxicity Value(s)

As described above, subchronic osRfDs associated with each health effect are presented as they may be useful for certain decision purposes (i.e., site-specific risk assessments with less-than-lifetime exposures). The osRfD values selected were associated with decreased serum anti-tetanus antibody concentrations for immune effects and decreased total T4 levels for thyroid effects. Confidence in each osRfD is described in Table 5-10 and consider confidence in the study used to derive the quantitative estimate, the overall health effect, specific evidence base, and quantitative estimate for each osRfD.

#### Selection of Subchronic RfD and Confidence Statement

Organ-/system-specific subchronic RfD values for PFHxS selected in the previous section are summarized in Table 5-11.

Table 5-11 Subchronic RfD organ-/system-specific RfD values for PFHxS

Subchronic reference dose (RfD)
Basis | RfD (mg/kg-d) | | Confidence
Immune (developmental) effects | 4 × 10^−10^ | | Medium
Subchronic organ-/system-specific RfDs
Organ/system | Outcomes and studies | POD_[underlined: HED]_ (mg/kg-d) | UF_C_ | osRfD (mg/kg-d) | Confidence
Thyroid | Decreased serum T4 (free) in F1 Wistar rats Ramhøj et al. (2018) | 2.45 × 10^−5^; (NOAEL) | 100 | 2 × 10^−7^ | Medium
Immune (developmental) | Decreased serum anti-tetanus and anti-diphtheria antibody concentrations measured in children at age 7 with PFHxS exposure measured at age 5 Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018); Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018) 1.16–1.23 × 10^−9^ | 1.16 × 10^−8^ and 1.23 × 10^−8^; (BMDL_½SD_) | 30 | 4 × 10^−10^ | Medium

From the identified targets of PFHxS toxicity and derived subchronic osRfDs (see Table 5-10), an RfD of 4 × 10^−10^ mg/kg-day based on decreased serum anti-tetanus and diphtheria antibody concentrations in children is selected for less-than-lifetime exposure. Confidence in the RfD is medium, based on medium confidence in the immune osRfD, as described in Table 5-8. The considerations for selecting the immune osRfD for the lifetime RfD are the same as those applied in selecting the subchronic RfD.

### 5.2.3 Inhalation Reference Concentration (RfC) Derivation

No studies examining inhalation effects of short-term, subchronic, chronic, or gestational exposure for PFHxS in humans or animals have been identified, precluding the derivation of an RfC.

## 5.3 CANCER TOXICITY VALUES

Considering the limitations in the PFHxS evidence base on cancer (see Section 3.3) and in accordance with the Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005), EPA concluded that based on the available evidence, a classification of “Inadequate Information to Assess Carcinogenic Potential” of PFHxS in humans. The lack of adequate carcinogenicity data for PFHxS precludes the derivation of quantitative estimates of cancer for either oral (e.g., an oral slope factor [OSF]) or inhalation (e.g., an inhalation unit risk [IUR]) PFHxS exposure.

38 Percentage increase = (e^β^-1)*100) see Kim et al. (2023).