# 4 SUMMARY OF HAZARD IDENTIFICATION CONCLUSIONS

## 4.1 SUMMARY OF CONCLUSIONS FOR NONCANCER HEALTH EFFECTS

As described in detail in Section 3, the currently available evidence indicates that exposure to perfluorohexanesulfonic acid [PFHxS] and its related salts likely results in thyroid (see Section 3.2.1) and immune (see Section 3.2.2) effects in humans given sufficient PFHxS exposure conditions. These judgments are based primarily on data from epidemiologic studies for immune effects and on short-term (28-day exposure), and reproductive (gestational and postnatal exposure) oral exposure studies in rodents for thyroid effects. Further characterizations of the exposure conditions relating to these two identified hazards are provided in Section 5.

The hazard identification judgment that the evidence indicates PFHxS exposure is likely to cause thyroid toxicity, specifically decreased thyroid hormones, in humans given sufficient PFHxS exposure conditions, is based primarily on a short-term study and two multigenerational studies in rats reporting a consistent and coherent pattern of hormonal changes at PFHxS exposure levels ≥2.5 mg/kg-day. A consistent dose-dependent decrease of T4, and to a lesser extent T3, in adult and juvenile rats, with a magnitude of effect (up to 70%) in the absence of effects in TSH was observed (with males being more sensitive). In addition, one multigenerational study reported increased incidence of minimal thyroid hypertrophy and moderate hyperplasia in male rats after PFHxS exposure. Because of the similarities in thyroid hormone production between rodents and humans, the effects in rodents were considered relevant to humans. A detailed discussion of thyroid effects is included in Section 3.2.1.

The hazard identification judgment that the evidence indicates PFHxS exposure is likely to cause immunotoxicity in humans given sufficient exposure conditions is based on generally consistent evidence of reduced antibody response to vaccination at median blood concentrations of 0.2–0.6 ng/mL in children. The direction of association was generally consistent across studies and timing of exposure and outcome measures, although not all the results were statistically significant. Further, three studies reported higher odds of infectious disease with higher PFHxS exposure, including total infectious disease, lower respiratory infection, throat infection, pseudocroup, and gastroenteritis. Lastly, there was some evidence of hypersensitivity, based primarily on a single well-conducted study of asthma, although findings were inconsistent across studies. A detailed discussion of immune effects is included in Section 3.2.2.

The evidence suggests but is not sufficient to infer that, given sufficient exposure conditions, PFHxS exposure may result in adverse health effects on the hepatic, cardiometabolic, renal, and neurodevelopmental systems, along with developmental effects. These judgments highlight the notable data gaps and uncertainties identified in the available epidemiological and experimental animal PFHxS studies (see Section 3.2.3, Section 3.2.4, Section 3.2.5, and Section 3.2.6). The uncertainties in the above-mentioned hazards were considered too large for developing toxicity values (see Section 5). However, to convey some sense of the magnitude of a potential estimate for developmental effects, calculations based on this suggestive evidence are provided for comparison purposes. The objective was to inform the database uncertainty factor (UF) for quantitative estimates of thyroid and immune effects.

For all other health effects described in Section 3 (i.e., male, and female reproductive, hematopoietic, and other noncancer effects) the evidence is inadequate to assess whether PFHxS exposure might cause effects in humans. No quantitative estimates were attempted for these health effects.

The potential for multiorgan effects of PFHxS exposure exists. As an example, the reported hypertrophy and hyperplasia in the follicular epithelium cells of the thyroid and in the centrilobular hepatocytes in the F0 male rats exposed to 10 mg/kg-day PFHxS (Butenhoff et al., 2009) may be related effects. It has been shown that exposure to compounds that cause microsomal enzyme induction in the liver can result in a compensatory hypertrophy and hyperplasia of the thyroid due to increased plasma turnover of T4 and TSH (Sanders et al., 1988; Butenhoff et al., 2009). However, as discussed in Section 3.2.1, the authors did not measure thyroid hormones as part of their study design and therefore the reported observation that thyroid hypertrophy and hyperplasia are compensatory mechanisms due to turnover of T4 and TSH is speculative. In addition, decreases in T3 and T4 observed in adult and juvenile animals exposed to PFHxS could be linked to metabolic effects as well as neurodevelopmental effects such as cognitive decline in children discussed in detail Section 3.2.1). Lastly, the decreased immune response observed in children exposed to PFHxS could lead to increased risk of infection as well as cancer (Germolec et al., 2022), although neither of these latter effects were well-studied in the available PFHxS evidence base.

Table 4-1 Hazard conclusions across published EPA PFAS human health assessments

Health outcome | PFAS assessments^a,b,c^
Health outcome | PFHxS | PFDA | PFHxA | PFBA | PFBS | Gen X chemicals | PFOA | PFOS
Endocrine/ Thyroid | + | − | + | + | + | ND | Human: + | Human: +/−; Animal: +/−
Endocrine/ Thyroid | + | − | + | + | + | ND | Animal: +/− | Human: +/−; Animal: +/−
Hepatic/Liver | +/− | + | + | + | − | + | Human: +; Animal: + | Human: −
Hepatic/Liver | +/− | + | + | + | − | + | Human: +; Animal: + | Animal: +
Developmental | +/− | + | + | + | + | +/− | Human: +; Animal: + | Human: +; Animal: +
Reproductive | − | + | − | − | − | +/− | Human: − | ND
Reproductive | − | + | − | − | − | +/− | Animal: +/− | ND
Immunotoxicity | + | + | − | − | − | +/− | Human: +; Animal: + | Human: +/−
Immunotoxicity | + | + | − | − | − | +/− | Human: +; Animal: + | Animal: +
Renal | − | − | − | − | + | +/− | Human: +/−; Animal: +/− | ND
Hematopoietic/Hematological | − | − | + | − | ND | +/− | ND | ND
Ocular | − | − | ND | − | ND | ND | ND | ND
Serum Lipids | − | +/− | ND | ND | − | ND | Human: +; Animal: + | Human: +
Hyperglycemia | − | − | ND | ND | ND | ND | Human: −; Animal: − | Animal: +/−
Nervous System | − | +/− | − | ND | ND | ND | Human: −; Animal: − | Animal: +/−
Cardiovascular | − | +/− | ND | ND | − | ND | ND | ND
Cancer | − | − | − | − | − | +/− | +/− | +/−

a Assessments used multiple approaches for summarizing their noncancer hazard conclusion scales; for comparison purposes, the conclusions are presented as follows: ‘+’ = evidence demonstrates or evidence indicates (e.g., PFHxA), or evidence supports (e.g., PFBS); ‘+/−‘ = suggestive evidence, ’−‘ = inadequate evidence (e.g., PFHxA) or equivocal evidence (e.g., PFBS); ‘−/−‘ = sufficient evidence to conclude no hazard (no assessment drew this conclusion); ND = no data available for this outcome for this PFAS.

b The assessments all followed the EPA carcinogenicity guidelines (U.S. EPA, 2005) a similar presentation to that used to summarize the noncancer judgments is applied for the cancer hazard conclusions, as follows: ‘+’ = carcinogenic to humans or likely to carcinogenic to humans;’+/−‘ = suggestive evidence of carcinogenic potential; ‘−‘ = inadequate information to assess carcinogenic potential; ‘−/−‘ = not likely to be carcinogenic to humans(no assessment drew this conclusion); ND = no carcinogenicity data available for this PFAS.

c The hazard conclusions for the various EPA PFAS assessments presented in this table were not considered during evidence integration and thus did not inform the evidence integration conclusions presented in the PFHxA assessment. Published EPA PFAS human health assessments: U.S. EPA PFDA (U.S. EPA, 2023a), PFHxA (U.S. EPA, 2023b), PFBA (U.S. EPA, 2022b), PFBS (U.S. EPA, 2021b), Gen X Chemicals (U.S. EPA, 2021a), PFOA (U.S. EPA, 2024b), and PFOS (U.S. EPA, 2024a).

## 4.2 SUMMARY OF CONCLUSIONS FOR CARCINOGENICITY

The evidence currently available to make a judgment as to whether PFHxS exposure might affect the development of any specific cancers is scant, inconsistent, and limited to low confidence studies. Consistent with EPA guidance (U.S. EPA, 2005) to apply a standard descriptor as part of the hazard narrative and to express a conclusion regarding the weight of evidence for the carcinogenic hazard potential, a descriptor of inadequate information to assess carcinogenic potential is applied for PFHxS.

## 4.3 CONCLUSIONS REGARDING SUSCEPTIBLE POPULATIONS AND LIFESTAGES

Understanding the potential areas of susceptibility to the identified human health hazards of PFHxS can help to inform expectations of variability in responses across individuals, as well as uncertainties and confidence in candidate toxicity values (see Section 5.2). The available human and animal evidence indicate that early lifestages represent a susceptible population for the adverse effects of PFHxS exposure. High confidence experimental studies report alterations in thyroid function, including reduced serum T4 and T3, after gestational and early postnatal PFHxS exposures in rats (see Section 3.2.1). In addition, medium confidence epidemiological studies report that exposure to PFHxS was associated with decreased immune response after routine vaccinations against tetanus and diphtheria vaccines in children at ages 5 and 7 (see Section 3.2.2). Although there are considerable uncertainties in the developmental epidemiological database (e.g., potential impact on PFHxS biomarkers due to pregnancy hemodynamics), consistent and coherent epidemiological findings on fetal growth restriction including several medium and high confidence developmental epidemiological studies also provide support for examination of critical in utero exposure windows (see Section 3.2.3).

The significant difference in clearance between male and female rats (7.2 vs. 84.1 mL/kg-day, respectively; see Section 3.1.4 for details) implies a sex-dependent susceptibility in that species: for given dose, blood and tissue levels are predicted and were observed to be significantly higher in male rats than female rats. While clearance levels in male and female mice were quite similar to each other (3.9 and 3.2 mL/kg-day), the markedly lower clearance in female mice compared with female rats predicts a strong species difference for susceptibility to developmental effects. Clearance values for adult humans are consistently much lower than observed in either mice or rats (0.02–0.07 mL/kg-day), which is predicted to result in a strong species difference in susceptibility. However, only one of the human studies that directly evaluated clearance observed a clear sex difference, with (geometric mean) urinary clearance in younger women being about 50% higher than men and older women (Zhang et al. (2013b); see Table 3-4). Additional clearance due to menstrual fluid loss could significantly reduce internal doses in women of childbearing age. The rate of menstrual fluid clearance estimated by Verner and Longnecker (2015) (0.033 mL/kg-day) is only slightly lower than (80% of) the geometric mean clearance for fecal and urinary elimination (0.041 mL/kg-day), so blood levels in a 30-year-old woman might be 55% of those in a 30-year-old man exposed to the same dose (Jain and Ducatman, 2022). (EPA’s analysis of PFNA concentrations from NHANES in never-pregnant women ages versus men 20–52 years of age yielded a geometric mean ratio of 56.75%.) In addition, serial blood measurement of PFHxS in pregnant women show that the decrease in clearance due to the lack of menstruation during pregnancy does not result in an increase in internal dose (Oh et al., 2022). This implies that other pharmacokinetic changes during pregnancy mediate the decreased clearance during that time and that the clearance for women of reproductive age (prior to pregnancy) is also appropriate for evaluating maternal dosimetry for developmental endpoints in humans. Animal-to-human extrapolations do account for the species- and sex-specific clearance observed among mice and rats, so in that regard PK-related susceptibility is addressed.

Jain and Ducatman (2019c) observed 32% and 40% higher geometric mean PFHxS concentrations in individuals with glomerular function designated GF-2 and GF-3A, reflecting mild-moderate stages of kidney disease, respectively, vs. GF-1 (p < 0.01), though those with the most severe kidney disease had PFHxS levels indistinguishable from GF-1. The results likely reflect that GF-2 and GF-3A levels of disease decrease renal clearance of PFHxS, which in turn will lead to higher risk of (other) adverse effects to individuals in this group. The impact, however, is in the range of the pharmacokinetic portion of the human inter-individual uncertainty factor, i.e., is less than UF_H,PK_ = 3.

Given the effects seen in the developing individuals (i.e., altered thyroid and immune functions), prenatal and early postnatal lifestages represent a potentially sensitive population for the effects of PFHxS exposure. No evidence was available to inform other factors that could inform the potential for susceptibility to PFHxS exposure including demographics, genetic variability, health status other than renal function, behaviors or practices or social determinants. The potential impact of these other susceptibility factors remains unknown.