# 2 LITERATURE SEARCH AND STUDY EVALUATION RESULTS

## 2.1 LITERATURE SEARCH AND SCREENING RESULTS

The database searches yielded 4,432 records; of these records 162 were identified from additional sources, such as posted National Toxicology Program (NTP) study tables and during review of reference lists from other authoritative sources (ATSDR, 2021) (see Figure 2-1). No studies were submitted to EPA. After deduplication, 1,935 unique records were identified, 862 were excluded during title and abstract screening, and 806 were reviewed at the full text level. Of the 806 screened at the full text level, 445 were considered to meet the populations, exposures, comparators, and outcomes (PECO) eligibility criteria (see Table 1-4). The studies meeting PECO at the full text level included 415 epidemiologic studies and 20 animal studies. High-throughput screening data on perfluorohexane sulfonate (PFHxS) are currently available from the EPA’s Chemicals Dashboard (U.S. EPA, 2019b) and relevant information is presented and analyzed in Appendix D (see Section 2).

Figure 2-1 Literature search for perfluorohexanesulfonic acid and related salts

## 2.2 STUDY EVALUATION RESULTS

Four hundred fifteen epidemiologic studies were identified that met the PECO criteria and report on the potential association between PFHxS and human health effects. The database of animal toxicity studies for PFHxS consists of two short-term oral exposure studies using rats (NTP, 2018a; 3M, 2000a), two short-term study in mice (Viberg et al., 2013; Das et al., 2017), three subchronic studies using mice (Yin et al., 2021; He et al., 2022; Bijland et al., 2011), and five multigenerational studies using rats or mice (Tetzlaff et al., 2021; Ramhøj et al., 2018; Ramhøj et al., 2020; Marques et al., 2021; Chang et al., 2018; Butenhoff et al., 2009; 3M, 2003) and one chronic study in C57BL/6j mice (Pfohl et al., 2020).

Graphical representations of outcome-specific study evaluations are presented and discussed within the hazard sections (see Sections 3.2.1−3.3.1). In cases for which a study was rated medium or low confidence for one or more of the evaluated outcomes, the specific limitations are explained in the synthesis section(s). Detailed rationales for each domain and overall confidence rating are available in Health Assessment Workspace Collaborative (HAWC (https://hawcprd.epa.gov/assessment/100500074/)).