# 1 OVERVIEW OF BACKGROUND INFORMATION AND ASSESSMENT METHODS

A series of five PFAS assessments (Perfluorohexanesulfonic acid [PFHxS], perfluorohexanoic acid [PFHxA], perfluorobutanoic acid [PFBA], perfluorononanoic acid [PFNA], perfluorodecanoic acid [PFDA], and their associated salts; see December 2018 IRIS Outlook (https://www.epa.gov/sites/production/files/2018-12/documents/iris_program_outlook_december_2018.pdf)) is being developed by the Integrated Risk Information System (IRIS) Program at the request of the U.S. Environmental Protection Agency (EPA) national programs and regions. Appendix A is the systematic review protocol for these five PFAS assessments. The protocol outlines the scoping and problem-formulation efforts relating to these assessments, including a summary of other federal and state reference values for PFHxS. The protocol also lays out the systematic review and dose-response methods used to conduct this review (see also Section 1.2). This systematic review protocol was released for public comment in November 2019 and was subsequently updated based on those public comments. Appendix A includes a link to the updated protocol, including a summary of the updates in the protocol history section (see Section 12). In addition to these ongoing IRIS PFAS toxicity assessments, EPA’s Office of Research and Development is carrying out several other activities related to PFAS, including creation of PFAS systematic evidence maps (SEMs) and consolidating and updating PFAS data on chemical and physical properties, human health toxicity, and pharmacokinetics, as well as ecotoxicity.

## 1.1 BACKGROUND INFORMATION ON PERFLUOROHEXANESULFONIC ACID (PFHxS)

Section 1.1 provides a brief overview of aspects of the physicochemical properties, human exposure, and environmental fate characteristics of perfluorohexanesulfonic acid (PFHxS; CASRN 335-46-4), and its related salts that might provide useful context for this assessment. This overview is not intended to provide a comprehensive description of the available information on these topics. The reader is encouraged to refer to the source materials cited below, more recent publications on these topics, and authoritative reviews or assessments focused on these topics.

### 1.1.1 Physical and Chemical Properties

PFHxS and its related salts such as potassium, sodium, and ammonium PFHxS salts covered in this assessment are members of the group per- and polyfluoroalkyl substances (PFAS). Buck et al. (2011) defines PFAS as fluorinated substances that “contain 1 or more C atoms on which all the H substituents (present in the nonfluorinated analogs from which they are notionally derived) have been replaced by F atoms, in such a manner that they contain the perfluoroalkyl moiety C_n_F_2n+1_–).” More specifically, PFHxS is classified as a perfluoroalkane sulfonic acid [PFSA; (OECD, 2015)]. PFSAs containing six or more perfluorinated carbons are considered long-chain PFASs (OECD, 2015; Buck et al., 2011; ATSDR, 2021). Thus, PFHxS is a long-chain PFAS. The chemical structures of PFHxS and its related salts are presented in Figure 1-1.^2^ The physical-chemical properties of PFHxS and related salts are provided in Table 1-1.

Figure 1-1 Chemical structure of PFHxS and related salts (see https://comptox.epa.gov/dashboard/)

X represents the cations for potassium (CASRN 3871-99-6), sodium (CASRN 82382-12-5), and ammonium (CASRN 68259-08-5).

Table 1-1 Physical-chemical properties of PFHxS and related salts^a^

Property (unit) | Value
Property (unit) | PFHxS 355-46-4^b^ | PFHxS Potassium salt 3871-99-6^c^ | PFHxS Ammonium salt 68259-08-5^c^ | PFHxS Sodium salt 82382-12-5^c^
Molecular weight (g/mol) | 400 | 438 | 417c^*^ | 422^*^
Melting point (°C) | 190 | 273 | 111^*^ | 217^*^
Boiling point (°C) | 246 | 303^*^ | 228 * | 238^*^
Density (g/cm^3^) | 1.84^*^ | 1.84^*^ | 1.84^*^ | 1.84^*^
Vapor pressure (mm Hg) | 8.10 × 10^−9^ | 8.19 × 10^−9^* | 8.19 × 10^−9^* | 8.19 × 10^−9^*
Henry’s law constant (atm-m^3^/mol) | 1.94 × 10^−10^* | 1.94 × 10^−10^* | 1.94 × 10^−10^* | 1.94 × 10^−10^*
Water solubility (mol/L) | 6.08 × 10^−4d^ | 3.52 × 10^−2^* | 6.10 × 10^−4^* | 7.03 × 10^−2^*
pKa | 0.14^*^ | ND | ND | ND
LogP | 2.20^d^ | 2.71^*^ | 3.48^*^ | 2.91^*^
Soil adsorption coefficient (L/kg) | 2,300^*^ | 2,300^*^ | 2,300^*^ | 2,300^*^
Bioconcentration factor (BCF) | 175^*^ | 271^*^ | 271^*^ | 5.94^*^

* Average predicted value. These values are more uncertain and, in general, less reliable than experimental values. ND = no data.

a This information is provided as part of a general overview providing background context only and should not be used for decision purposes. Up-to-date primary references should be consulted. A summary of pharmacokinetic parameters used for this evaluation is provided in Table 3-6 and the method for calculating the human equivalent dose values (prior to application of UFs) is described in Approach for Animal-Human Extrapolation of PFHxS Dosimetry Section 3.1.7.

b CompTox Chemicals Dashboard (https://comptox.epa.gov/dashboard/) (U.S. EPA, 2018a) for all values except pKa. The value of pKa was obtained from ECHA: https://echa.europa.eu/documents/10162/1f48372e-97dd-db9f-4335-8cec7ae55eee. Questions and corrections to the CompTox Chemicals Dashboard can be submitted at: https://comptox.epa.gov/dashboard/.

c (U.S. EPA, 2018a). Questions and corrections to the CompTox Chemicals Dashboard can be submitted at: https://comptox.epa.gov/dashboard/.

d As of April 2023 these values are indicated as ‘experimental’ in the CompTox Chemicals Dashboard (U.S. EPA, 2018a); however, they appear to be predicted values based on the citations provided, and therefore may be more uncertain. Note that these values are not used for dosimetric extrapolation in this assessment, which was based on available empirical pharmacokinetic data (see Section 3.1.7).

### 1.1.2 Sources, Production, and Use

PFAS are not naturally occurring in the environment (ATSDR, 2024). They are manmade compounds that have been used widely over the past several decades in consumer products and industrial applications because of their resistance to heat, oil, stains, grease, and water. PFHxS has been used as a surfactant to make fluoropolymers, and in water and stain-protective coatings for carpets, paper, packaging, and textiles (NTP, 2018c; Norwegian Environment Agency, 2018). It may also be present in certain industrial and consumer products, such as electronics, industrial fluids, “food-contact papers, water-proofing agents, cleaning and polishing products either for intentional uses (as surfactants or surface protection agents) or as unintentional impurities from industrial production processes” (Norwegian Environment Agency, 2018). It has also been used in aqueous film-forming foam (AFFF) for fire suppression (Laitinen et al., 2014).

EPA has been working with companies in the fluorochemical industry since the early 2000s to phase out the production and use of long-chain PFAS such as PFHxS (https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/risk-management-and-polyfluoroalkyl-substances-pfass). However, in addition to the environmental persistence of PFHxS (see below), products containing PFHxS are still in use and may be imported into the United States; thus, there may continue to be a source of environmental contamination due to disposal or breakdown in the environment (Kim and Kannan, 2007).

No chemical reporting data on production volume are available in EPA’s ChemView (U.S. EPA, 2019a) for PFHxS or its salts. As part of the National Defense Authorization Act for Fiscal Year 2020 (see Section 7321), 172 per- and polyfluoroalkyl substances including PFHxS were added to the EPA’s Toxic Release Inventory (TRI) list (https://www.epa.gov/toxics-release-inventory-tri-program/tri-listed-chemicals). The reporting requirements apply to a de minimus limit of 1% and a manufacture process, or otherwise use a threshold of 100 pounds. Currently, incomplete quantitative information is available in EPA’s Toxic Release Inventory or other informational repositories regarding PFHxS releases to the environment from facilities that manufacture, process, or use imported/previously manufactured products that contain or dispose of imported/previously manufactured products containing PFHxS.

### 1.1.3 Environmental Fate and Transport

PFAS, including PFHxS, are very stable and persistent in the environment (Harbison et al., 2015; ATSDR, 2024), and many are found worldwide in the environment, wildlife, and humans (https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/risk-management-and-polyfluoroalkyl-substances-pfass). Long-chain PFAS have been found at sites, including private and federal facilities, and have been associated with various sources, including AFFF for fire suppression, and PFAS manufacturers and industries that use PFAS (e.g., textiles) (ATSDR, 2024).

PFAS that are released to air exist in the vapor phase in the atmosphere and resist photolysis, but particle-bound concentrations have also been measured (Kim and Kannan, 2007).

In soil, the mobility of PFHxS depends on the soil adsorption coefficients (see Table 1-1). Volatilization of PFHxS from moist soil is not expected to be an important transport process (NLM, 2013, 2016, 2017). Furthermore, PFHxS is expected to adsorb to suspended solids and sediments in water (NLM, 2013, 2016, 2017).

### 1.1.4 Potential for Human Exposure and Populations with Potentially Greater Exposure

The general population may be exposed to PFAS via inhalation of indoor or outdoor air, ingestion of drinking water and food, and dermal contact with PFAS-containing products (NLM, 2013, 2017; ATSDR, 2024). Exposure may also occur via hand-to-mouth transfer of materials containing these compounds (ATSDR, 2024). However, the oral route of exposure has been considered the most important route of exposure among the general population. This conclusion is based on several studies that have investigated the various routes of PFAS exposure (Sunderland et al., 2019).

The presence of PFHxS in human blood provides evidence of exposure among the general population. PFHxS has been monitored in the human population as part of the National Health and Nutrition Examination Survey (NHANES). PFHxS was measured in serum samples collected in 2013–2014 from more than 2,000 survey participants (CDC, 2022). The results of these analyses are presented in Table 1-2.

Table 1-2 Serum PFHxS concentrations based on NHANES 2013–2014 data (µg/L)

Population group^a^ | Value
Total population (N = 2,168); Geometric mean; 50th percentile; 95th percentile | 1.35; 1.40; 5.60
3 to 5 yr (N = 181); Geometric mean; 50th percentile; 95th percentile | 0.715; 0.740; 1.62
6 to 11 yr (N = 458); Geometric mean; 50th percentile; 95th percentile | 0.913; 0.850; 4.14
12 to 19 yr (N = 402); Geometric mean; 50th percentile; 95th percentile | 1.27; 1.10; 6.30
20 yr and older (N = 1,766); Geometric mean; 50th percentile; 95th percentile | 1.36; 1.40; 5.50

Source: CDC (2022). Fourth National Report on Human Exposure to Environmental Chemicals.

a This table provides only general context on serum PFHxS levels from a single study and within a narrow time period (environmental PFHxS levels are changing over time). Note that PFHxS is expected to bioaccumulate over a lifetime (see Sections 1.1.3 and 3.1). Up-to-date information from authoritative bodies should be used in any decisional context.

#### Air and Dust

PFHxS has not been evaluated under the Air Toxics Screening Assessment (https://www.epa.gov/AirToxScreen). However, PFHxS was measured at concentrations ranging from less than the limit of detection to 1.56 pg/m^3^ in the vapor and particle phases of air samples collected from an urban area of Albany, New York, in 2006 (Kim and Kannan, 2007).

PFAS, including PFHxS, have also been measured in indoor air and dust and may be associated with the indoor use of consumer products such as PFAS-treated carpets or other textiles (ATSDR, 2024). For example, Kato et al. (2009) analyzed dust samples collected from 39 homes in the United States, United Kingdom, Germany, and Australia for PFAS, including PFHxS, which was detected in 79.5% of the samples. Furthermore, indoor air samples (N = 4) from a town in Norway had PFHxS mean concentrations of <4.1 pg/m^3^ for PFHxS (Barber et al., 2007).

#### Water

EPA conducted monitoring for several PFAS, including PFHxS, in drinking water as part of the third Unregulated Contaminant Monitoring Rule (UCMR) (U.S. EPA, 2016c). Under the UCMR3, all public water systems (PWSs) serving more than 10,000 people and a representative sample of 800 PWSs serving 10,000 or fewer people were monitored for 30 unregulated contaminants between January 2013 and December 2015. PFHxS was among the 30 contaminants monitored and was detected above the minimum reporting level (MRL) of 0.03 μg/L in 55 of the 4,920 PWSs tested and in 207 of the 36,971 samples collected. Kim and Kannan (2007) analyzed lake water, rainwater, snow, and surface water from Albany, New York, and reported concentrations of PFHxS ranging from less than the LOD to 0.0135 μg/L. PFAS were detected at higher concentrations in groundwater samples from an industrial site (3M Cottage Grove) in Minnesota. PFHxS was detected in all seven wells that were sampled at concentrations ranging from 6.47 to 40 μg/L (WS, 2007) as cited in ATSDR (2021). In additon UMCR5 is currently underway and will include monitoring requirements for 29 PFAS compounds, including PFHxS, in both small and large public water systems (over 10,000 systems combined), over the 2023 – 2025 timeframe. The minimum reporting limit (MRL) for PFHxS under UCMR5 is 0.003 μg/L, which is 10-times lower than that required under UCMR3, and sufficient to determine potential impacts below the MCL of 10 μg/L (https://www.epa.gov/system/files/documents/2022-02/ucmr5-factsheet.pdf).

#### Aqueous Film-Forming Foam (AFFF) Training and Military Sites

The levels of PFHxS in soil and sediment surrounding perfluorochemical industrial facilities have been measured at concentrations ranging from less than the LOD to 3,470 ng/g (ATSDR, 2021). PFHxS was also detected at an Australian training ground where AFFFs had been used (Baduel et al., 2015). PFHxS was detected at 10 U.S. military sites in 76.9% of the surface soil samples and 72.7% of sediment samples (ATSDR, 2021). Table 1-3 shows the concentration of PFHxS in soil and sediment at these military sites.

Table 1-3 PFHxS levels at 10 military installations

Media | Value
Surface Soil; Frequency of detection (%); Median (µg/kg); Maximum (µg/kg) | 76.92; 5.70; 1,300
Subsurface Soil; Frequency of detection (%); Median (µg/kg); Maximum (µg/kg) | 59.62; 4.40; 520
Sediment; Frequency of detection (%); Median (µg/kg); Maximum (µg/kg) | 72.73; 9.10; 2,700
Surface Water; Frequency of detection (%); Median (µg/L); Maximum (µg/L) | 88.00; 0.710; 815
Groundwater; Frequency of detection (%); Median (µg/L); Maximum (µg/L) | 94.93; 0.870; 290

Source: Anderson et al. (2016); ATSDR (2024).

#### Other Exposures

Schecter et al. (2012) collected 10 samples of 31 food items from five grocery stores in Texas and analyzed them for persistent organic pollutants, including PFHxS, which was detected in cod fish at a concentration of 0.07 ng/g wet weight. Stahl et al. (2014) characterized PFAS in freshwater fish from 164 U.S. urban river sites and 157 Great Lakes sites. PFHxS was detected in 45% of the samples at maximum concentrations of 3.5 ng/g and method detection limit of 0.12 ng/g (Stahl et al., 2014). PFHxS was not detected in U.S. grocery store finfish and shellfish samples (Ruffle et al., 2020). Apart from fish, overall dietary data for the United States are limited. Data from other countries (e.g., South Korea, Brazil, Saudi Arabia) suggest that long-chain PFAS such as PFHxS can sometimes be detected in samples of food products including shellfish, dairy products, meats, vegetables, food packaging materials, infant formula, and water (both tap and bottled) (Surma et al., 2017; Pérez et al., 2014; Moreta and Tena, 2014; Lakind et al., 2023; Heo et al., 2014; Chen et al., 2018b). The relevance of these detects (and the associated PFHxS levels) to U.S. products is unknown.

#### Populations with Potentially Greater Exposures

Populations that may experience exposures greater than those of the general population may include individuals in occupations that require frequent contact with PFHxS-containing products, such as individuals who install and treat carpets or firefighters (ATSDR, 2024). Rotander et al. (2015a) analyzed serum samples from 149 Australian firefighters at an AFFF training facility. Mean and median PFHxS concentrations were 10 to 15 times higher than those of the general population of Australia and Canada. Laitinen et al. (2014) evaluated eight firefighters’ exposure to PFHxS after three training sessions in Finland in which AFFF had been used. The authors found that the firefighters “serum PFHxS concentrations seemed to increase during the three training sessions although it was not the main PFAS used in AFFF.” Populations living near fluorochemical facilities where environmental contamination has occurred may also be more highly exposed (ATSDR, 2021).

Populations that rely primarily on seafood for most of their diet, possibly including some Native American tribes (Byrne et al., 2017), may also be disproportionately exposed to PFHxS. Christensen et al. (2017) and Haug et al. (2010) used data on serum PFAS levels and 30-day self-reported fish and shellfish ingestion rates from NHANES 2007−2014 to explore potential relationships between PFAS exposures and fish consumption. PFHxS was detected in the serum of 99% of the NHANES participants, and after adjusting for demographic characteristics shellfish consumption was associated with elevated levels of PFHxS (Christensen et al., 2017).

## 1.2 SUMMARY OF ASSESSMENT METHODS

The methods used to conduct this systematic review and dose-response analysis are summarized in the remainder of this section. A more detailed description of the methods for each step of the assessment development process is provided in the systematic review protocol released in 2019 (see Appendix A); the literature inventory for PFHxS in the protocol was not updated after its release (see Section 2.1). The protocol includes additional problem-formulation details, including the specific aims and key science issues identified for this assessment.

### 1.2.1 Literature Search and Screening

The detailed search approach, including the query strings and populations, exposures, comparators, and outcomes (PECO) criteria (see Table 1-4), are provided in Appendix B. The results of the literature search and screening efforts are documented in Section 2.1. Briefly, a literature search was first conducted in 2017, and regular yearly updates are performed. The most recent literature search update that was fully incorporated into the assessment is from April 2022. A literature search was also performed in April of 2023. However, only studies through April 2022 are fully incorporated into the assessment. Studies available after April 2022 were only fully incorporated if they would have a material impact on the assessment conclusions (for additional details please see Appendix B and Table B-5). The results of this literature update and any additional unscreened studies identified during public comment were screened against the PECO criteria and presented in a table that was included as an Appendix to the assessment (Appendix B, Table B-5). The table provides the identified studies that met PECO criteria or certain supplemental evidence categories (i.e., in vivo mechanistic or MOA studies, including non-PECO routes of exposure and populations; in vitro and in silico models; and ADME and pharmacokinetic studies) and EPA’s judgment on whether the studies have a material impact on the assessment conclusions (i.e., identified hazards or toxicity values) presented in the public comment draft. The external peer reviewers were asked to consider EPA’s disposition of these newly identified studies and make recommendations, as appropriate (see Charge Question 1).

The literature search queried the following databases (no date or language restrictions were applied):

- PubMed (National Library of Medicine (https://www.ncbi.nlm.nih.gov/pubmed/))
- Web of Science (Thomson Reuters (https://apps.webofknowledge.com/))
- Toxline (National Library of Medicine (https://datadiscovery.nlm.nih.gov/Drugs-and-Chemicals/Toxicology-Information-Online-TOXLINE-RETIRED-/txmx-urgu/about_data))
- TSCATS (Toxic Substances Control Act Test Submissions (https://cfpub.epa.gov/si/si_public_record_Report.cfm?dirEntryId=2855))

In addition, relevant literature not found through database searching was identified by:

- Review of citations in studies meeting the PFHxS PECO criteria or published reviews of PFHxS; finalized or publicly available U.S. federal and international assessments (e.g., the 2021 Agency for Toxic Substances and Disease Registry [ATSDR] Toxicological Profile for Perfluoroalkyls).
- Searches of published PFAS Systematic Evidence Maps (SEMs) (Pelch et al., 2022; Carlson et al., 2022) starting in 2021.
- Review of studies submitted to federal regulatory agencies and brought to the attention of EPA. For example, studies submitted to EPA by the manufacturers in support of requirements under the Toxic Substances Control Act (TSCA).
- Identification of studies during literature screening for other EPA PFAS assessments. For example, epidemiology studies relevant to PFHxS were sometimes identified by searches focused on one of the other four PFAS currently being assessed by the Integrated Risk Information System (IRIS) Program.
- Other gray literature (e.g., primary studies not indexed in typical databases, such as technical reports from government agencies or scientific research groups; unpublished laboratory studies conducted by industry; or working reports/white papers from research groups or committees) brought to the attention of EPA.

All literature is tracked in the U.S. EPA Health and Environmental Research Online (HERO) database (https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/2630). The PECO criteria (see Table 1-4) identify the evidence that addresses the specific aims of the assessment and to focus the literature screening, including study inclusion/exclusion.

Table 1-4 Populations, exposures, comparators, and outcomes (PECO) criteria

PECO element | Evidence
[underlined: P]opulations | Human: Any population and lifestage (occupational or general population, including children and other sensitive populations). The following study designs will be included: controlled exposure, cohort, case control, and cross sectional. (Note: Case reports and case series will be tracked as potential supplemental material.); Animal: Nonhuman mammalian animal species (whole organism) of any lifestage (including preconception, in utero, lactation, peripubertal, and adult stages).; Other: In vitro, in silico, or nonmammalian models of genotoxicity. (Note: Other in vitro, in silico, or nonmammalian models will be tracked as potential supplemental material.)
[underlined: E]xposures | Human: Studies providing quantitative estimates of PFHxS exposure based on administered dose or concentration, biomonitoring data (e.g., urine, blood, or other specimens), environmental or occupational-setting measures (e.g., water levels or air concentrations, residential location and/or duration, job title, or work title). (Note: Studies that provide qualitative, but not quantitative, estimates of exposure will be tracked as supplemental material.); Animal: Oral or inhalation studies including quantified exposure to PFHxS based on administered dose, dietary level, or concentration. (Note: Nonoral and noninhalation studies will be tracked as potential supplemental material). PFHxS mixture studies are included if they employ an experimental arm that involves exposure to a single PFHxS. (Note: Other PFHxS mixture studies are tracked as potential supplemental material.); Studies must address exposure to following: PFHxS (CASRN 355-46-4), PFHxS potassium salt (CASRN 3871-99-6) or PFHxS ammonium salt (CASRN 68259-08-5).
[underlined: C]omparators | Human: A comparison or reference population exposed to lower levels (or no exposure/exposure below detection levels) or for shorter periods of time.; Animal: Includes comparisons to historical controls^a^ or a concurrent control group that is unexposed, exposed to vehicle-only or air-only exposures. (Note: Experiments including exposure to PFHxS across different durations or exposure levels without including one of these control groups will be tracked as potential supplemental material [e.g., for evaluating key science issues; Section 2.4 of the protocol].)
[underlined: O]utcomes | All cancer and noncancer health outcomes. (Note: Other than genotoxicity studies, studies including only molecular endpoints [e.g., gene or protein changes; receptor binding or activation] or other nonphenotypic endpoints addressing the potential biological or chemical progression of events contributing toward toxic effects will be tracked as potential supplemental material [e.g., for evaluating key science issues; Section 2.4 of the protocol].)

a While concurrent controls are strongly preferred, historical controls can be useful, for example in the evaluation of rare tumors or when considering the similarity between current experimental animals and laboratory conditions to historical controls. However, use of historical controls only is noted as a limitation during study evaluation, so concurrent and historical controls are not considered equal. It is noted that no studies using only historical controls were identified in the literature searches for PFHxS.

In addition to those studies meeting the PECO criteria and studies excluded as not relevant to the assessment, studies containing supplemental material potentially relevant to the specific aims of the assessment were inventoried during the literature screening process. Although these studies did not meet PECO criteria, they were not excluded. Rather, they were considered for use in addressing the identified key science issues (see Appendix A, Section 2.4) and other potential scientific uncertainties identified during assessment development but unanticipated at the time of protocol posting. Studies categorized as “potentially relevant supplemental material” included the following:

- In vivo mechanistic or mode of action studies, including non-PECO routes of exposure (e.g., intraperitoneal injection) and populations (e.g., nonmammalian models)
- In vitro and in silico models
- Absorption, distribution, metabolism, and excretion (ADME) and pharmacokinetic studies (excluding models)^3^
- Exposure assessment or characterization (no health outcome) studies
- Human case reports or case series studies

The literature was screened by two independent reviewers with a process for conflict resolution, first at the title and abstract level and subsequently the full-text level, using structured forms in DistillerSR (Evidence Partners; https://www.distillersr.com/products/distillersr-systematic-review-software). Literature inventories for PECO-relevant studies and studies tagged as “potentially relevant supplemental material” during screening were created to facilitate subsequent review of individual studies or sets of studies by topic-specific experts.

### 1.2.2 Evaluation of Individual Studies

The detailed approaches used for the evaluation of epidemiologic and animal toxicological studies used in the PFHxS assessment are provided in the systematic review protocol (see Appendix A, Section 6). The general approach for evaluating PECO-relevant health effect studies is the same for epidemiology and animal toxicological studies, although the specifics of applying the approach differ; thus, they are described in detail in Appendix A (see Sections 6.2 and 6.3, respectively). Approaches for study evaluation for mechanistic studies are described in detail in Appendix A (see Section 6.5).

The key concerns for the review of epidemiology and animal toxicological studies are potential bias (systematic errors or deviations from the truth related to internal validity that affect the magnitude or direction of an effect in either direction) and insensitivity (factors that limit the ability of a study to detect a true effect and can lead to a false negative). For example, any type of random measurement error that may lead to attenuation of study results (i.e., bias toward the null). In evaluating individual studies, two or more reviewers independently arrived at judgments regarding the reliability of the study results (reflected as study confidence determinations; see below) with regard to each outcome or outcome grouping of interest; thus, different judgments were possible for different outcomes within the same study. The results of these reviews were tracked within EPA’s version of the Health Assessment Workplace Collaboration (HAWC (https://hawc.epa.gov/assessment/100500074/)). To develop these judgments, each reviewer assigned a category of good, adequate, deficient (or not reported, which generally carried the same functional interpretation as deficient), or critically deficient (listed from best to worst methodological conduct; see Appendix A, Section 6 for definitions) related to each evaluation domain representing the different characteristics of the study methods that were evaluated based on the criteria outlined in HAWC.

Once all evaluation domains were evaluated, the reviewers collectively considered the identified strengths and limitations to reach a final study confidence classification:

- High confidence: No notable deficiencies or concerns were identified; the potential for bias is unlikely or minimal, and the study used sensitive methodology.
- Medium confidence: Possible deficiencies or concerns were noted, but the limitations are unlikely to be of a notable degree or to have a notable impact on the results.
- Low confidence: Deficiencies or concerns were noted, and the potential for bias or inadequate sensitivity could have a significant impact on the study results or their interpretation. Low confidence results were given less weight than high or medium confidence results during evidence synthesis and integration (see Sections 1.2.4 and 1.2.5).
- Uninformative: Serious flaw(s) were identified that make the study results unusable. Uninformative studies were not considered further, except to highlight possible research gaps.

Using the HAWC platform (and conflict resolution by an additional reviewer, as needed), the reviewers reached a consensus judgment regarding each evaluation domain and overall (confidence) determination. The specific limitations identified during study evaluation were carried forward to inform the synthesis (see Section 1.2.4) within each body of evidence for a given health effect (i.e., study confidence determinations were not used to inform judgments in isolation).

#### Additional Epidemiology Considerations

While the detailed methods for epidemiology study evaluation are described in the IRIS PFAS systematic review protocol ((U.S. EPA, 2021c) see Appendix A, Section 6.2.1), a few considerations have been developed further; these are described here.

As noted above, study sensitivity is an important consideration given that it could lead to false negative (i.e., null) results (Type II error) if a study is underpowered or not designed with adequate sensitivity to detect an association that may exist. A key element for study sensitivity, along with others described in the systematic review protocol, is whether exposure contrasts/gradients are sufficient across populations to detect differences in risk. For example, measurement error resulting in inaccurate exposure estimates can lead to exposure misclassification and influence the ability to detect an association as well as an exposure-response relationship that may be evident of a biologic gradient.

Confounding across PFAS is a potential source of uncertainty when interpreting the results of epidemiology studies of individual PFAS (e.g., quantifying the effect of an individual PFAS can potentially be confounded by other PFAS). For confounding to occur, co-pollutants would have to be associated with PFAS of interest, associated with the endpoint, and not act as an intermediate in the causal pathway. One way to begin to assess whether co-exposure is occurring is through examination of correlations. While some PFAS pairs have correlation coefficients consistently above 0.6 (e.g., PFNA and PFDA), the correlations for most PFAS, including PFHxS, vary from 0.1 to 0.6 depending on the study (see Appendix A, Section 6). For this reason, it was not considered appropriate to assume that co-exposure to other PFAS was necessarily an important confounder in all studies. The potential for confounding across PFAS is incorporated in individual study evaluations and assessed across studies in evidence synthesis. In most studies, it is difficult to determine the likelihood of confounding without considering additional information not typically included in individual study evaluation (e.g., associations of other PFAS with the outcome of interest and correlation profiles of PFAS within and across studies). In addition, even when this information is considered or the study authors perform analyses to adjust for other PFAS, it is often not possible to fully disentangle the associations due to high correlations. This challenge stems from the potential for amplification bias in which bias can occur following adjustment of highly correlated PFAS (Weisskopf et al., 2018). Thus, in most studies, there may be some residual uncertainty about the risk of confounding by other PFAS. A “Good” rating for the confounding domain is reserved for situations in which there is minimal concern for substantial confounding across PFAS as well as for other sources of confounding. Examples that would obtain this rating include results for a PFAS that predominates in a population (such as a contamination event) or studies that demonstrate robust results following multi-PFAS adjustment (i.e., similar results to single-PFAS models), which would also indicate minimal concern for amplification bias. Because of the challenge in evaluating individual studies for confounding across PFAS, this issue is also assessed across studies during the evidence synthesis phase, as described in the systematic review protocol (see link in Appendix A, Section 6.2), primarily when there is support for an association with adverse health effects in the epidemiology evidence (i.e., moderate, or robust evidence in humans, as described below). Analyses used include comparing results across studies in populations with different PFAS exposure mixture profiles, considering results of multipollutant models when available, and examining strength of associations for other correlated PFAS. In situations for which there is considerable uncertainty regarding the impact of residual confounding across PFAS, a factor is captured that decreases the overall strength of evidence (see link in Appendix A, Section 10).

### 1.2.3 Data Extraction

The detailed data extraction approach is provided in Appendix A, Section 8. Briefly, data extraction and content management were carried out using HAWC for all health effects for animal studies and some health effects for epidemiological studies. Data extraction elements collected from epidemiological, controlled human exposure, animal toxicological, and in vitro studies are described in HAWC (https://hawcprd.epa.gov/about/). For epidemiological studies not extracted in HAWC, extraction was performed into Word tables and the extraction elements depended on information needed for presentation. Not all studies that meet the PECO criteria went through data extraction: studies evaluated as being uninformative were not considered further and therefore did not undergo data extraction, and outcomes determined to be less relevant during PECO refinement did not go through data extraction. The same was true for low confidence studies when medium and high confidence studies (e.g., on an outcome) were available. All findings are considered for extraction, regardless of the statistical significance of their findings. The level of extraction for specific outcomes within a study may differ (i.e., ranging from a narrative to full extraction of dose-response effect size information). For quality control, data extraction was performed by one member of the evaluation team and independently verified by at least one other member. Discrepancies in data extraction were resolved by discussion or consultation within the evaluation team.

### 1.2.4 Evidence Synthesis and Integration

For the purposes of this assessment, evidence synthesis and integration are considered distinct but related processes (see Appendix A, Sections 9 and 10 for full details). For each assessed health effect, the evidence syntheses provide a summary discussion of each body of evidence considered in the review that directly informs the integration across evidence to draw an overall judgment for each health effect. The available human and animal evidence pertaining to the potential health effects are synthesized separately, with each synthesis providing a summary discussion of the available evidence that addresses considerations regarding causation that are adapted from Hill (1965). Mechanistic evidence is also synthesized as necessary to help inform key decisions regarding the human and animal evidence; processes for synthesizing mechanistic information are covered in detail in Appendix A, Section 9.2.

The syntheses of the human and animal health effects evidence focus on describing aspects of the evidence that best inform causal interpretations, including the exposure context examined in the sets of studies. The evidence synthesis is based primarily on studies of high and medium confidence. Low confidence studies could be used if few or no studies with higher confidence are available to help evaluate consistency, or if the study designs of the low confidence studies address notable uncertainties in the set of high or medium confidence studies on a given health effect. If low confidence studies are used, a careful examination of the study evaluation and sensitivity with potential effects on the evidence synthesis conclusions will be included in the narrative. When possible, results across studies are compared using graphs and charts or other data visualization strategies. The synthesis of mechanistic information informs the integration of health effects evidence for both hazard identification (e.g., biological plausibility or coherence of the available human or animal evidence; inferences regarding human relevance, or the identification of susceptible populations and lifestages across the human and animal evidence) and dose-response evaluation (e.g., selection of benchmark response levels, selection of uncertainty factors). Evaluations of mechanistic information typically differ from evaluations of phenotypic evidence (e.g., from routine toxicological studies) primarily because mechanistic data evaluations consider the support for and involvement of specific events or sets of events within the context of a broader research question (e.g., support for a hypothesized mode of action; consistency with known biological processes), rather than evaluations of individual apical endpoints considered in relative isolation.

Following the synthesis of human and animal health effects data and mechanistic data, integrated judgments are drawn across all lines of evidence for each assessed health effect. During evidence integration, a structured and documented two-step process is used, as follows:

Building from the separate syntheses of human and animal evidence, the strength of the evidence from the available human and animal health effect studies are summarized in parallel, but separately, using a structured evaluation of an adapted set of considerations first introduced by Sir Bradford Hill (Hill, 1965). This process is similar to that used by the Grading of Recommendations Assessment, Development, and Evaluation (GRADE) (Schünemann et al., 2011; Morgan et al., 2016; Guyatt et al., 2011), which arrives at an overall integration conclusion based on consideration of the body of evidence. These summaries incorporate the relevant mechanistic evidence (or mode of action [MOA] understanding) that informs the biological plausibility and coherence within the available human or animal health effect studies. The terms associated with the different strength-of-evidence judgments within evidence streams are robust, moderate, slight, indeterminate, and compelling evidence of no effect.

The animal, human, and mechanistic evidence judgments are then combined to draw an overall judgment that incorporates inferences across evidence streams. Specifically, the inferences considered during this integration include the human relevance of the animal and mechanistic evidence, coherence across the separate bodies of evidence, and other important information (e.g., judgments regarding susceptibility). Note that without evidence to the contrary, the human relevance of animal findings is assumed. The final output is a summary judgment of the evidence base for each potential human health effect across evidence streams. The terms associated with these summary judgments are evidence demonstrates, evidence indicates (likely), evidence suggests, evidence inadequate, and strong evidence of no effect. The decision points within the structured evidence integration process are summarized in an evidence profile table for each considered health effect.

As discussed in the protocol (see Appendix A), the methods for evaluating the potential carcinogenicity of PFAS follow processes laid out in the EPA cancer guidelines (U.S. EPA, 2005); however, for PFHxS, data relevant to cancer were sparse and did not allow for such an evaluation (see Appendix A, Section 3.3).

### 1.2.5 Dose-Response Analysis

The details for the dose-response employed in this assessment can be found in Appendix A, Section 11. Briefly, a dose response assessment was performed for noncancer health hazards, following exposure to PFHxS via the oral route, as supported by existing data. For oral noncancer hazards, oral reference doses (RfDs) are derived when possible. An RfD is an estimate, with uncertainty spanning perhaps an order of magnitude, of an exposure to the human population (including susceptible subgroups) that is likely to be without an appreciable risk of deleterious health effects over a lifetime (U.S. EPA, 2002). The derivation of a reference value like the RfD depends on the nature of the health hazard conclusions drawn during evidence integration. For noncancer outcomes, a dose response assessment was conducted for evidence integration conclusions of evidence demonstrates or evidence indicates (likely). In general, toxicity values are not developed for noncancer hazards with evidence suggests conclusions (see Appendix A, Section 10.2 for exceptions). Consistent with EPA practice, the PFHxS assessment applied a two-step approach for dose response assessment that distinguishes analysis of the dose response data in the range of observation from any inferences about responses at lower environmentally relevant exposure levels (U.S. EPA, 2005, 2012):

- Within the observed dose range, the preferred approach was to use dose-response modeling to incorporate as much of the dataset as possible into the analysis. This modeling to derive a point of departure (POD) ideally includes an exposure level near the lower end of the range of observation, without significant extrapolation to lower exposure levels.
- As derivation of cancer risk estimates and reference values nearly always involves extrapolation to exposures lower than the POD; the approaches to be applied in these assessments are described in more detail in Appendix A, Section 11.2.

When sufficient and appropriate human and laboratory animal data are available for the same outcome, human data are generally preferred for the dose-response assessment because use of human data eliminates the need to perform interspecies extrapolations. For reference values, this assessment will derive a candidate value from each suitable dataset. Evaluation of these candidate values will yield a single organ/system-specific value for each organ/system under consideration from which a single overall reference value will be selected to cover all health outcomes across all organs/systems. While this overall reference value represents the focus of these dose-response assessments, the organ/system-specific values can be useful for subsequent cumulative risk assessments that consider the combined effect of multiple PFAS (or other agents) acting at a common organ/system. For noncancer toxicity values, uncertainties in these estimates are characterized and discussed.

For dose-response purposes, EPA has developed a standard set of models (http://www.epa.gov/bmds) that can be applied to typical datasets, including those that are nonlinear. In situations for which there are alternative models with significant biological support (e.g., pharmacodynamic models), those models are included as alternatives in the assessment(s) along with a discussion of the models’ strengths and uncertainties. EPA has developed guidance on modeling dose-response data, assessing model fit, selecting suitable models, and reporting modeling results [see the EPA Benchmark Dose Technical Guidance (U.S. EPA, 2012)]. For each modeled response, a POD from the observed data was estimated to mark the beginning of extrapolation to lower doses. The POD is an estimated dose (expressed in human-equivalent terms) near the lower end of the observed range without significant extrapolation to lower doses. The POD is used as the starting point for subsequent extrapolations and analyses. For noncancer effects, the POD is used in calculating the RfD.

2 While this figure shows the linear chemical structures, the assessment may also apply to other nonlinear isomers of PFHxS, and related salts as described in the Executive Summary.

3 Given the known importance of ADME data, this supplemental tagging was used as the starting point for a separate screening and review of pharmacokinetics data (see Appendix A, Section 9.2 for details).