# REFERENCES

3M (3M Company). (1999). The science of organic fluorochemistry. (EPA-HQ-OPPT-2002-0043-0006). https://www.regulations.gov/document/EPA-HQ-OPPT-2002-0043-0006.
3M (3M Company). (2000). Sanitized report: Exploratory 28-day oral toxicity study with telomer alcohol, telomer acrylate, PFHS and PFOS (positive control) by daily gavage in the rat followed by a 14/28-day recovery period [TSCA Submission]. (FYI-0500-01378 B; DCN 84000000018). St. Paul, MN. https://yosemite.epa.gov/oppts/epatscat8.nsf/ReportSearchView/05ADDF3067814C978525703B004B4119.
ACOG (American College of Obstetricians and Gynecologists). (2020). How your fetus grows during pregnancy. Available online at https://www.acog.org/womens-health/faqs/how-your-fetus-grows-during-pregnancy
Agarwal, S; Cunningham-Rundles, C. (2007). Assessment and clinical interpretation of reduced IgG values. Ann Allergy Asthma Immunol 99: 281–283. 10.1016/S1081-1206(10)60665-5.17910333
Aker, A; Ayotte, P; Caron-Beaudoin, É; Ricard, S; Gaudreau, É; Lemire, M. (2023). Cardiometabolic health and per and polyfluoroalkyl substances in an Inuit population. Environ Int 181: 108283. 10.1016/j.envint.2023.108283.37883911
Alkhalawi, E; Kasper-Sonnenberg, M; Wilhelm, M; Völkel, W; Wittsiepe, J. (2016). Perfluoroalkyl acids (PFAAs) and anthropometric measures in the first year of life: Results from the Duisburg Birth Cohort. J Toxicol Environ Health A 79: 1041–1049. 10.1080/15287394.2016.1219552.27924715
Alsen, M; Leung, AM; van Gerwen, M. (2023). Per- and Polyfluoroalkyl Substances (PFAS) in Community Water Systems (CWS) and the Risk of Thyroid Cancer: An Ecological Study. Toxics 11: 786. 10.3390/toxics11090786.37755796
American Heart Association. (2022). What is Cholesterol? Dallas, TX. https://www.heart.org/en/health-topics/cholesterol/about-cholesterol#:~:text=High%20cholesterol%20is%20one%20of,the%20higher%20your%20 overall%20risk.
Ames, JL; Burjak, M; Avalos, LA; Braun, JM; Bulka, CM; Croen, LA; Dunlop, AL; Ferrara, A; Fry, RC; Hedderson, MM; Karagas, MR; Liang, D; Lin, PID; Lyall, K; Moore, B; Morello-Frosch, R; O’Connor, TG; Oh, J; Padula, AM; Woodruff, TJ; Zhu, Y; Hamra, GB. (2023). Prenatal exposure to per- and polyfluoroalkyl substances and childhood autism-related outcomes. Epidemiology 34: 450–459. 10.1097/EDE.0000000000001587.36630444
Ammitzbøll, C; Börnsen, L; Petersen, ER; Oturai, AB; Søndergaard, HB; Grandjean, P; Sellebjerg, F. (2019). Perfluorinated substances, risk factors for multiple sclerosis and cellular immune activation. J Neuroimmunol 330: 90–95. 10.1016/j.jneuroim.2019.03.002.30852181
Amstutz, VH; Cengo, A; Sijm, DTH, M; Vrolijk, MF. (2022). The impact of legacy and novel perfluoroalkyl substances on human cytochrome P450: An in vitro study on the inhibitory potential and underlying mechanisms. Toxicology 468: 153116. 10.1016/j.tox.2022.153116.35121066
Angrish, MM; Kaiser, JP; Mcqueen, CA; Chorley, BN. (2016). Tipping the balance: Hepatotoxicity and the 4 apical key events of hepatic steatosis [Review]. Toxicol Sci 150: 261–268. 10.1093/toxsci/kfw018.26980302
Annunziato, KM; Jantzen, CE; Gronske, MC; Cooper, KR. (2019). Subtle morphometric, behavioral and gene expression effects in larval zebrafish exposed to PFHxA, PFHxS and 6:2 FTOH. Aquat Toxicol 208: 126–137. 10.1016/j.aquatox.2019.01.009.30669116
Arrebola, JP; Ramos, JJ; Bartolomé, M; Esteban, M; Huetos, O; Cañas, AI; López-Herranz, A; Calvo, E; Pérez-Gómez, B; Castaño, A; BIOAMBIENT.ES. (2019). Associations of multiple exposures to persistent toxic substances with the risk of hyperuricemia and subclinical uric acid levels in BIOAMBIENT.ES study. Environ Int 123: 512–521. 10.1016/j.envint.2018.12.030.30622076
Ashley-Martin, J; Dodds, L; Arbuckle, TE; Bouchard, MF; Fisher, M; Morriset, AS; Monnier, P; Shapiro, GD; Ettinger, AS; Dallaire, R; Taback, S; Fraser, W; Platt, RW. (2017). Maternal concentrations of perfluoroalkyl substances and fetal markers of metabolic function and birth weight. Am J Epidemiol 185: 185–193. 10.1093/aje/kww213.28172036
ATSDR (Agency for Toxic Substances and Disease Registry). (2021). Toxicological profile for perfluoroalkyls [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. 10.15620/cdc:59198.
Averina, M; Brox, J; Huber, S; Furberg, AS; Sørensen, M. (2019). Serum perfluoroalkyl substances (PFAS) and risk of asthma and various allergies in adolescents. The Tromsø study Fit Futures in Northern Norway. Environ Res 169: 114–121. 10.1016/j.envres.2018.11.005.30447498
Averina, M; Huber, S; Almås, B; Brox, J; Jacobsen, BK; Furberg, AS; Grimnes, G. (2024). Early menarche and other endocrine disrupting effects of per- and polyfluoroalkyl substances (PFAS) in adolescents from Northern Norway. The Fit Futures study. Environ Res 242: 117703. 10.1016/j.envres.2023.117703.37984785
Bach, CC; Bech, BH; Nohr, EA; Olsen, J; Matthiesen, NB; Bonefeld-Jørgensen, EC; Bossi, R; Henriksen, TB. (2016a). Perfluoroalkyl acids in maternal serum and indices of fetal growth: The Aarhus Birth Cohort. Environ Health Perspect 124: 848–854. 10.1289/ehp.1510046.26495857
Bach, CC; Vested, A; Jørgensen, KT; Bonde, JP; Henriksen, TB; Toft, G. (2016b). Perfluoroalkyl and polyfluoroalkyl substances and measures of human fertility: a systematic review [Review]. Crit Rev Toxicol 46: 735–755. 10.1080/10408444.2016.1182117.27268162
Bassler, J; Ducatman, A; Elliott, M; Wen, S; Wahlang, B; Barnett, J; Cave, MC. (2019). Environmental perfluoroalkyl acid exposures are associated with liver disease characterized by apoptosis and altered serum adipocytokines. Environ Pollut 247: 1055–1063. 10.1016/j.envpol.2019.01.064.30823334
Batzella, E; Zare Jeddi, M; Pitter, G; Russo, F; Fletcher, T; Canova, C. (2022). Associations between Mixture of Perfluoroalkyl Substances and Lipid Profile in a Highly Exposed Adult Community in the Veneto Region. Int J Environ Res Public Health 19. 10.3390/ijerph191912421.
Beck, IH; Bilenberg, N; Möller, S; Nielsen, F; Grandjean, P; Højsager, FD; Halldorsson, TI; Nielsen, C; Jensen, TK. (2023). Association Between Prenatal and Early Postnatal Exposure to Perfluoroalkyl Substances and IQ Score in 7-Year-Old Children From the Odense Child Cohort. Am J Epidemiol 192: 1522–1535. 10.1093/aje/kwad110.37119029
Behr, AC; Lichtenstein, D; Braeuning, A; Lampen, A; Buhrke, T. (2018). Perfluoroalkylated substances (PFAS) affect neither estrogen and androgen receptor activity nor steroidogenesis in human cells in vitro. Toxicol Lett 291: 51–60. 10.1016/j.toxlet.2018.03.029.29601859
Benskin, JP; De Silva, AO; Martin, LJ; Arsenault, G; Mccrindle, R; Riddell, N; Mabury, SA; Martin, JW. (2009). Disposition of perfluorinated acid isomers in Sprague-Dawley rats; part 1: single dose. Environ Toxicol Chem 28: 542–554. 10.1897/08-239.1.18939892
Berntsen, HF; Bjørklund, CG; Strandabø, R; Haug, TM; Moldes-Anaya, A; Fuentes-Lazaro, J; Verhaegen, S; Paulsen, RE; Tasker, RA; Ropstad, E. (2018). PFOS-induced excitotoxicity is dependent on Ca2+ influx via NMDA receptors in rat cerebellar granule neurons. Toxicol Appl Pharmacol 357: 19–32. 10.1016/j.taap.2018.08.015.30144469
Bessone, F; Razori, MV; Roma, MG. (2019). Molecular pathways of nonalcoholic fatty liver disease development and progression. Cell Mol Life Sci 76: 99–128. 10.1007/s00018-018-2947-0.30343320
Beste, LA; Icardi, M; Hunt, CM; Gylys-Colwell, I; Lowry, E; Taylor, L; Morgan, TR; Chang, MF; Maier, MM; Cheung, R. (2020). Alanine aminotransferase results differ by analyzer manufacturer in a national integrated health setting, 2012-2017. Arch Pathol Lab Med 144: 748–754. 10.5858/arpa.2018-0622-OA.31697169
Betancourt, MJ; Girolami, M. (2013). Hamiltonian monte carlo for hierarchical models. Betancourt, MJ; Girolami, M. 10.48550/arXiv.1312.0906.
Bjerregaard-Olesen, C; Bach, CC; Long, M; Ghisari, M; Bech, BH; Nohr, EA; Henriksen, TB; Olsen, J; Bonefeld-Jørgensen, EC. (2016). Determinants of serum levels of perfluorinated alkyl acids in Danish pregnant women. Int J Hyg Environ Health 219: 867–875. 10.1016/j.ijheh.2016.07.008.27451073
Bjerregaard-Olesen, C; Bach, CC; Long, M; Wielsøe, M; Bech, BH; Henriksen, TB; Olsen, J; Bonefeld Jørgensen, EC. (2019). Associations of Fetal Growth Outcomes with Measures of the Combined Xenoestrogenic Activity of Maternal Serum Perfluorinated Alkyl Acids in Danish Pregnant Women. Environ Health Perspect 127: 17006. 10.1289/EHP1884.30676078
Bjork, JA; Dawson, DA; Krogstad, JO; Wallace, KB. (2021). Transcriptional effects of binary combinations of PFAS in FaO cells. Toxicology 464: 152997. 10.1016/j.tox.2021.152997.34695511
Björvang, RD; Hassan, J; Stefopoulou, M; Gemzell-Danielsson, K; Pedrelli, M; Kiviranta, H; Rantakokko, P; Ruokojärvi, P; Lindh, CH; Acharya, G; Damdimopoulou, P. (2021). Persistent organic pollutants and the size of ovarian reserve in reproductive-aged women. Environ Int 155: 106589. 10.1016/j.envint.2021.106589.33945905
Blomberg, A; Mortensen, J; Weihe, P; Grandjean, P. (2022). Bone mass density following developmental exposures to perfluoroalkyl substances (PFAS): a longitudinal cohort study. Environ Health 21: 113. 10.1186/s12940-022-00929-w.36402982
Boafo, YS; Mostafa, S; Obeng-Gyasi, E. (2023). Association of Combined Metals and PFAS with Cardiovascular Disease Risk. Toxics 11: 979. 10.3390/toxics11120979.38133380
Bonefeld-Jørgensen, EC. (2022). RE: Hjermitslev et al. Persistent organic pollutants in Greenlandic pregnant women and indices of foetal growth: The ACCEPT study.
Boobis, AR; Doe, JE; Heinrich-Hirsch, B; Meek, ME; Munn, S; Ruchirawat, M; Schlatter, J; Seed, J; Vickers, C. (2008). IPCS framework for analyzing the relevance of a noncancer mode of action for humans [Review]. Crit Rev Toxicol 38: 87–96. 10.1080/10408440701749421.18259981
Borenstein, M; Hedges, LV; Higgins, JPT; Rothstein, HR. (2009). Introduction to meta-analysis. Chichester, UK: John Wiley & Sons. 10.1002/9780470743386.
Borghese, MM; Liang, CL; Owen, J; Fisher, M. (2022). Individual and mixture associations of perfluoroalkyl substances on liver function biomarkers in the Canadian Health Measures Survey. Environ Health 21: 85. 10.1186/s12940-022-00892-6.36104725
Boucher, JM; Cousins, I; Scheringer, M; Hungerbuhler, K; Wang, Z. (2019). Toward a comprehensive global emission inventory of C_4-C_10 perfluoroalkanesulfonic acids (PFSAS) and related precursors: Focus on the life cycle of C_6- and C_10-based products [Letter]. Environ Sci Technol Lett 6: 1–7. 10.1021/acs.estlett.8b00531.
Boyd, RI; Ahmad, S; Singh, R; Fazal, Z; Prins, GS; Madak Erdogan, Z; Irudayaraj, J; Spinella, MJ. (2022). Toward a Mechanistic Understanding of Poly- and Perfluoroalkylated Substances and Cancer [Review]. Cancers 14. 10.3390/cancers14122919.
Brantsæter, AL; Whitworth, KW; Ydersbond, TA; Haug, LS; Haugen, M; Knutsen, HK; Thomsen, C; Meltzer, HM; Becher, G; Sabaredzovic, A; Hoppin, JA; Eggesbø, M; Longnecker, MP. (2013). Determinants of plasma concentrations of perfluoroalkyl substances in pregnant Norwegian women. Environ Int 54: 74–84. 10.1016/j.envint.2012.12.014.23419425
Brosset, E; Ngueta, G. (2022). Exposure to per- and polyfluoroalkyl substances and glycemic control in older US adults with type 2 diabetes mellitus. Environ Res 216: 114697. 10.1016/j.envres.2022.114697.36334831
Buck, CO; Eliot, MN; Kelsey, KT; Calafat, AM; Chen, A; Ehrlich, S; Lanphear, BP; Braun, JM. (2018). Prenatal exposure to perfluoroalkyl substances and adipocytokines: the HOME Study. Pediatr Res 84: 854–860. 10.1038/s41390-018-0170-1.30250302
Buck Louis, GM; Zhai, S; Smarr, MM; Grewal, J; Zhang, C; Grantz, KL; Hinkle, SN; Sundaram, R; Lee, S; Honda, M; Oh, J; Kannan, K. (2018). Endocrine disruptors and neonatal anthropometry, NICHD Fetal Growth Studies - Singletons. Environ Int 119: 515–526. 10.1016/j.envint.2018.07.024.30055518
Buckalew, AR; Wang, J; Murr, AS; Deisenroth, C; Stewart, WM; Stoker, TE; Laws, SC. (2020). Evaluation of potential sodium-iodide symporter (NIS) inhibitors using a secondary Fischer rat thyroid follicular cell (FRTL-5) radioactive iodide uptake (RAIU) assay. Arch Toxicol 94: 873–885. 10.1007/s00204-020-02664-y.32065294
Budtz-Jørgensen, E; Grandjean, P. (2018a). Application of benchmark analysis for mixed contaminant exposures: Mutual adjustment of perfluoroalkylate substances associated with immunotoxicity. PLoS ONE 13: e0205388. 10.1371/journal.pone.0205388.30339706
Budtz-Jørgensen, E; Grandjean, P. (2018b). Computational details for the paper “Application of benchmark analysis for mixed contaminant exposures: Mutual adjustment of perfluoroalkylate substances associated with immunotoxicity”.
Butenhoff, JL; Chang, SC; Ehresman, DJ; York, RG. (2009). Evaluation of potential reproductive and developmental toxicity of potassium perfluorohexanesulfonate in Sprague Dawley rats. Reprod Toxicol 27: 331–341. 10.1016/j.reprotox.2009.01.004.19429404
Callan, AC; Rotander, A; Thompson, K; Heyworth, J; Mueller, JF; Odland, JØ; Hinwood, AL. (2016). Maternal exposure to perfluoroalkyl acids measured in whole blood and birth outcomes in offspring. Sci Total Environ 569–570: 1107–1113. 10.1016/j.scitotenv.2016.06.177.
Cao, L; Guo, Y; Chen, Y; Hong, J; Wu, J; Hangbiao, J. (2022). Per-/polyfluoroalkyl substance concentrations in human serum and their associations with liver cancer. Chemosphere 296: 134083. 10.1016/j.chemosphere.2022.134083.35216980
Cao, L; Quan, XB; Zeng, WJ; Yang, XO; Wang, MJ. (2016). Mechanism of hepatocyte apoptosis [Review]. Journal of Cell Death 9: 19–29. 10.4137/JCD.S39824.28058033
Cao, W; Liu, X; Liu, X; Zhou, Y; Zhang, X; Tian, H; Wang, J; Feng, S; Wu, Y; Bhatti, P; Wen, S; Sun, X. (2018). Perfluoroalkyl substances in umbilical cord serum and gestational and postnatal growth in a Chinese birth cohort. Environ Int 116: 197–205. 10.1016/j.envint.2018.04.015.29698896
Cardenas, A; Hauser, R; Gold, DR; Kleinman, KP; Hivert, MF; Fleisch, AF; Lin, PD; Calafat, AM; Webster, TF; Horton, ES; Oken, E. (2018). Association of perfluoroalkyl and polyfluoroalkyl substances with adiposity. JAMA Netw Open 1: e181493. 10.1001/jamanetworkopen.2018.1493.30646133
Cardenas, A; Hivert, MF; Gold, DR; Hauser, R; Kleinman, KP; Lin, PD; Fleisch, AF; Calafat, AM; Ye, X; Webster, TF; Horton, ES; Oken, E. (2019). Associations of perfluoroalkyl and polyfluoroalkyl substances with incident diabetes and microvascular disease. Diabetes Care 42: 1824–1832. 10.2337/dc18-2254.31296647
Carlson, LA; Angrish, M; Shirke, AV; Radke, EG; Schulz, B; Kraft, A; Judson, R; Patlewicz, G; Blain, R; Lin, C; Vetter, N; Lemeris, C; Hartman, P; Hubbard, H; Arzuaga, X; Davis, A; Dishaw, LV; Druwe, IL; Hollinger, H; … Thayer, KA. (2022). Systematic evidence map for over one hundred and fifty per- and polyfluoroalkyl substances (PFAS) [Review]. Environ Health Perspect 130: 56001. 10.1289/EHP10343.35580034
Cellesi, C; Michelangeli, C; Rossolini, GM; Giovannoni, F; Rossolini, A. (1989). Immunity to diphtheria, six to 15 years after a basic three-dose immunization schedule. Journal of Biological Standardization 17: 29–34. 10.1016/0092-1157(89)90025-5.2921251
Chang, CJ; Barr, DB; Ryan, PB; Panuwet, P; Smarr, MM; Liu, K; Kannan, K; Yakimavets, V; Tan, Y; Ly, V; Marsit, CJ; Jones, DP; Corwin, EJ; Dunlop, AL; Liang, D. (2022). Per- and polyfluoroalkyl substance (PFAS) exposure, maternal metabolomic perturbation, and fetal growth in African American women: A meet-in-the-middle approach. Environ Int 158: 106964. 10.1016/j.envint.2021.106964.34735953
Chang, CJ; Ryan, PB; Smarr, MM; Kannan, K; Panuwet, P; Dunlop, AL; Corwin, EJ; Barr, DB. (2020). Serum per- and polyfluoroalkyl substance (PFAS) concentrations and predictors of exposure among pregnant African American women in the Atlanta area, Georgia. Environ Res 198: 110445. 10.1016/j.envres.2020.110445.33186575
Chang, S; Butenhoff, JL; Parker, GA; Coder, PS; Zitzow, JD; Krisko, RM; Bjork, JA; Wallace, KB; Seed, JG. (2018). Reproductive and developmental toxicity of potassium perfluorohexanesulfonate in CD-1 mice. Reprod Toxicol 78: 150–168. 10.1016/j.reprotox.2018.04.007.29694846
Chapman, AB; Abraham, WT; Zamudio, S; Coffin, C; Merouani, A; Young, D; Johnson, A; Osorio, F; Goldberg, C; Moore, LG; Dahms, T; Schrier, RW. (1998). Temporal relationships between hormonal and hemodynamic changes in early human pregnancy. Kidney Int 54: 2056–2063. 10.1046/j.1523-1755.1998.00217.x.9853271
Chen, L; Tong, C; Huo, X; Zhang, J; Tian, Y. (2021). Prenatal exposure to perfluoroalkyl and polyfluoroalkyl substances and birth outcomes: A longitudinal cohort with repeated measurements. Chemosphere 267: 128899. 10.1016/j.chemosphere.2020.128899.33220988
Chen, M; Zhu, L; Wang, Q; Shan, G. (2020a). Tissue distribution and bioaccumulation of legacy and emerging per-and polyfluoroalkyl substances (PFASs) in edible fishes from Taihu Lake, China. Environ Pollut 268: 115887. 10.1016/j.envpol.2020.115887.33120332
Chen, Y; Wu, Y; Lv, J; Zhou, S; Lin, S; Huang, S; Zheng, L; Deng, G; Feng, Y; Zhang, G; Feng, W. (2024). Overall and individual associations between per- and polyfluoroalkyl substances and liver function indices and the metabolic mechanism. Environ Int 183: 108405. 10.1016/j.envint.2023.108405.38163401
Chen, Z; Yang, T; Walker, DI; Thomas, DC; Qiu, C; Chatzi, L; Alderete, TL; Kim, JS; Conti, Q; Breton, CV; Liang, D; Hauser, ER; Jones, DP; Gilliland, FD. (2020b). Dysregulated lipid and fatty acid metabolism link perfluoroalkyl substances exposure and impaired glucose metabolism in young adults. Environ Int 145: 106091. 10.1016/j.envint.2020.106091.32892005
Chiu, WA; Lynch, MT; Lay, CR; Antezana, A; Malek, P; Sokolinski, S; Rogers, RD. (2022). Bayesian estimation of human population toxicokinetics of PFOA, PFOS, PFHxS, and PFNA from studies of contaminated drinking water. Environ Health Perspect 130: 127001. 10.1289/EHP10103.36454223
Christensen, KY; Raymond, MR; Thompson, BA; Anderson, HA. (2016). Fish consumption, levels of nutrients and contaminants, and endocrine-related health outcomes among older male anglers in Wisconsin. J Occup Environ Med 58: 668–675. 10.1097/JOM.0000000000000758.27253230
Christenson, B; Böttiger, M. (1986). Serological immunity to diphtheria in Sweden in 1978 and 1984. Scand J Infect Dis 18: 227–233. 10.3109/00365548609032331.3738433
Cohen, NJ; Yao, M; Midya, V; India-Aldana, S; Mouzica, T; Andra, SS; Narasimhan, S; Meher, AK; Arora, M; Chan, JKY; Chan, SY; Loy, SL; Minguez-Alarcon, L; Oulhote, Y; Huang, J; Valvi, D. (2023). Exposure to perfluoroalkyl substances and women’s fertility outcomes in a Singaporean population-based preconception cohort. Sci Total Environ 873: 162267. 10.1016/j.scitotenv.2023.162267.36801327
Cohn, BA; La Merrill, MA; Krigbaum, NY; Wang, M; Park, JS; Petreas, M; Yeh, G; Hovey, RC; Zimmermann, L; Cirillo, PM. (2020). In utero exposure to poly- and perfluoroalkyl substances (PFASs) and subsequent breast cancer. Reprod Toxicol 92: 112–119. 10.1016/j.reprotox.2019.06.012.31323350
Colicino, E; Pedretti, NF; Busgang, SA; Gennings, C. (2020). Per- and poly-fluoroalkyl substances and bone mineral density: Results from the Bayesian weighted quantile sum regression. Environmental Epidemiology 4: 1. 10.1097/EE9.0000000000000092.
Colles, A; Bruckers, L; Den Hond, E; Govarts, E; Morrens, B; Schettgen, T; Buekers, J; Coertjens, D; Nawrot, T; Loots, I; Nelen, V; De Henauw, S; Schoeters, G; Baeyens, W; van Larebeke, N. (2020). Perfluorinated substances in the Flemish population (Belgium): Levels and determinants of variability in exposure. Chemosphere 242: 125250. 10.1016/j.chemosphere.2019.125250.31896205
Collier, RJ. (1975). Diphtheria toxin: Mode of action and structure [Review]. Bacteriol Rev 39: 54–85. 10.1128/br.39.1.54-85.1975.164179
Cong, X; Liu, Q; Li, W; Wang, L; Feng, Y; Liu, C; Guo, LQ; Wang, L; Shi, C; Li, P. (2023). Systematic review and meta-analysis of breast cancer risks in relation to 2,3,7,8-tetrachlorodibenzo-p-dioxin and per- and polyfluoroalkyl substances [Review]. Environ Sci Pollut Res Int 30: 86540–86555. 10.1007/s11356-023-28592-9.37420152
Conway, B; Innes, KE; Long, D. (2016). Perfluoroalkyl substances and beta cell deficient diabetes. J Diabetes Complications 30: 993–998. 10.1016/j.jdiacomp.2016.05.001.27311784
Cui, F; Liu, H; Li, Y; Zheng, TZ; Xu, S; Xia, W; Sheng, X. (2022). Association of exposure to per- and polyfluoroalkyl substances with hemoglobin and hematocrit during pregnancy. Ecotoxicol Environ Saf 248: 114319. 10.1016/j.ecoenv.2022.114319.36423372
Dasgupta, S; Reddam, A; Liu, Z; Liu, J; Volz, DC. (2020). High-content screening in zebrafish identifies perfluorooctanesulfonamide as a potent developmental toxicant. Environ Pollut 256: 113550. 10.1016/j.envpol.2019.113550.31706782
Derakhshan, A; Kortenkamp, A; Shu, H; Broeren, MAC; Lindh, CH; Peeters, RP; Bornehag, CG; Demeneix, B; Korevaar, TIM. (2022). Association of per- and polyfluoroalkyl substances with thyroid homeostasis during pregnancy in the SELMA study. Environ Int 167: 107420. 10.1016/j.envint.2022.107420.35870378
DeWitt, JC; Germolec, DR; Luebke, RW; Johnson, VJ. (2016). Associating Changes in the Immune System with Clinical Diseases for Interpretation in Risk Assessment. Current Protocols in Toxicology 67: 1.1–18.11.22. 10.1002/0471140856.tx1801s67.
Ding, N; Harlow, SD; Randolph, JF; Calafat, AM; Mukherjee, B; Batterman, S; Gold, EB; Park, SK. (2020). Associations of perfluoroalkyl substances with incident natural menopause: The study of women’s health across the nation. J Clin Endocrinol Metab 105: E3169–E3182. 10.1210/clinem/dgaa303.32491182
Ding, N; Karvonen-Gutierrez, CA; Mukherjee, B; Calafat, AM; Harlow, SD; Park, SK. (2022). Per- and Polyfluoroalkyl Substances and Incident Hypertension in Multi-Racial/Ethnic Women: The Study of Women’s Health Across the Nation. Hypertension 79: 101161HYPERTENSIONAHA12118809. 10.1161/HYPERTENSIONAHA.121.18809.
Donat-Vargas, C; Bergdahl, IA; Tornevi, A; Wennberg, M; Sommar, J; Kiviranta, H; Koponen, J; Rolandsson, O; Åkesson, A. (2019a). Perfluoroalkyl substances and risk of type II diabetes: A prospective nested case-control study. Environ Int 123: 390–398. 10.1016/j.envint.2018.12.026.30622063
Donat-Vargas, C; Bergdahl, IA; Tornevi, A; Wennberg, M; Sommar, J; Koponen, J; Kiviranta, H; Åkesson, A. (2019b). Associations between repeated measure of plasma perfluoroalkyl substances and cardiometabolic risk factors. Environ Int 124: 58–65. 10.1016/j.envint.2019.01.007.30639908
Dufour, P; Pirard, C; Petrossians, P; Beckers, A; Charlier, C. (2020). Association between mixture of persistent organic pollutants and thyroid pathologies in a Belgian population. Environ Res 181: 108922. 10.1016/j.envres.2019.108922.31759644
Dunder, L; Salihovic, S; Elmståhl, S; Lind, PM; Lind, L. (2023). Associations between per- and polyfluoroalkyl substances (PFAS) and diabetes in two population-based cohort studies from Sweden. J Expo Sci Environ Epidemiol 33: 748–756. 10.1038/s41370-023-00529-x.36964247
Dzierlenga, M, .W.; Crawford, L, .; Longnecker, M, .P. (2020). Birth weight and perfluorooctane sulfonic acid: a random-effects meta-regression analysis. Environmental Epidemiology 4: e095. 10.1097/EE9.0000000000000095.33778349
Edwards, SW; Tan, YM; Villeneuve, DL; Meek, ME; McQueen, CA. (2016). Adverse outcome pathways—Organizing toxicological information to improve decision making [Review]. J Pharmacol Exp Ther 356: 170–181. 10.1124/jpet.115.228239.26537250
Eick, SM; Demicco, E; Valeri, L; Woodruff, TJ; Morello-Frosch, R; Hom Thepaksorn, EK; Izano, MA; Cushing, LJ; Wang, Y; Smith, SC; Gao, S; Park, JS; Padula, AM. (2020). Associations between prenatal maternal exposure to per- and polyfluoroalkyl substances (PFAS) and polybrominated diphenyl ethers (PBDEs) and birth outcomes among pregnant women in San Francisco. Environ Health 19: 100–100. 10.1186/s12940-020-00654-2.32938446
Eick, SM; Enright, EA; Geiger, SD; Dzwilewski, KLC; DeMicco, E; Smith, S; Park, JS; Aguiar, S; Woodruff, TJ; Morello-Frosch, R; Schantz, SL. (2021). Associations of maternal stress, prenatal exposure to per- and polyfluoroalkyl substances (PFAS), and demographic risk factors with birth outcomes and offspring neurodevelopment: An overview of the ECO.CA.IL prospective birth cohorts [Review]. Int J Environ Res Public Health 18: 742. 10.3390/ijerph18020742.33467168
Evans, N; Conley, JM; Cardon, M; Hartig, P; Medlock-Kakaley, E; Gray, LE, Jr. (2022). In vitro activity of a panel of per- and polyfluoroalkyl substances (PFAS), fatty acids, and pharmaceuticals in peroxisome proliferator-activated receptor (PPAR) alpha, PPAR gamma, and estrogen receptor assays. Toxicol Appl Pharmacol 449: 116136. 10.1016/j.taap.2022.116136.35752307
Fan, S; Wu, Y; Bloom, MS; Lv, J; Chen, L; Wang, W; Li, Z; Jiang, Q; Bu, L; Shi, J; Shi, T; Zeng, X; Zhang, L; Zhang, Z; Yang, B; Dong, G; Feng, W. (2023). Associations of per- and polyfluoroalkyl substances and their alternatives with bone mineral density levels and osteoporosis prevalence: A community-based population study in Guangzhou, Southern China. Sci Total Environ 862: 160617–160617. 10.1016/j.scitotenv.2022.160617.36462653
Fan, Y; Lu, C; Li, X; Xu, Q; Zhang, Y; Yang, X; Han, X; Du, G; Xia, Y; Wang, X. (2020). Serum albumin mediates the effect of multiple per- and polyfluoroalkyl substances on serum lipid levels. Environ Pollut 266 Pt 2: 115138. 10.1016/j.envpol.2020.115138.
Faquih, TO; Mook-Kanamori, DO; van Dijk, K, oW; Breteler, MMB; Landstra, EN; Vlieg, A, vanH; Aziz, NA; Li-Gao, R; de Mutsert, R; Rosendaal, FR; Noordam, R; van Heemst, D. (2024). Per- and Polyfluoroalkyl Substances Concentrations are Associated with an Unfavorable Cardio-Metabolic Risk Profile: Findings from Two Population-Based Cohort Studies. Exposure and Health. 10.1007/s12403-023-00622-4.
Fassler, CS; Pinney, SE; Xie, C; Biro, FM; Pinney, SM. (2019). Complex relationships between perfluorooctanoate, body mass index, insulin resistance and serum lipids in young girls. Environ Res 176: 108558. 10.1016/j.envres.2019.108558.31271921
Feng, Y; Bai, Y; Lu, Y; Chen, M; Fu, M; Guan, X; Cao, Q; Yuan, F; Jie, J; Li, M; Meng, H; Wang, C; Hong, S; Zhou, Y; Zhang, X; He, M; Guo, H. (2022a). Plasma perfluoroalkyl substance exposure and incidence risk of breast cancer: A case-cohort study in the Dongfeng-Tongji cohort. Environ Pollut 306: 119345. 10.1016/j.envpol.2022.119345.35472559
Feng, Y; Fu, M; Guan, X; Wang, C; Meng, H; Zhou, Y; He, M; Guo, H. (2022b). Associations of exposure to perfluoroalkyl substances with serum uric acid change and hyperuricemia among Chinese women: Results from a longitudinal study. Chemosphere 308: 136438. 10.1016/j.chemosphere.2022.136438.36116625
Fisher, M; Arbuckle, TE; Liang, CL; Leblanc, A; Gaudreau, E; Foster, WG; Haines, D; Davis, K; Fraser, WD. (2016). Concentrations of persistent organic pollutants in maternal and cord blood from the maternal-infant research on environmental chemicals (MIREC) cohort study. Environ Health 15: 59. 10.1186/s12940-016-0143-y.27142700
Fragki, S; Louisse, J; Bokkers, B; Luijten, M; Peijnenburg, A; Rijkers, D; Piersma, AH; Zeilmaker, MJ. (2023). New approach methodologies: A quantitative in vitro to in vivo extrapolation case study with PFASs. Food Chem Toxicol 172: 113559. 10.1016/j.fct.2022.113559.36535450
Freire, C; Vela-Soria, F; Castiello, F; Salamanca-Fernández, E; Quesada-Jiménez, R; López-Alados, MC; Fernandez, MF; Olea, N. (2023). Exposure to perfluoroalkyl substances (PFAS) and association with thyroid hormones in adolescent males. Int J Hyg Environ Health 252: 114219. 10.1016/j.ijheh.2023.114219.37451108
Fruchart, JC; Nierman, MC; Stroes, ES; Kastelein, JJ; Duriez, P. (2004). New risk factors for atherosclerosis and patient risk assessment [Review]. Circulation 109: III15–III19. 10.1161/01.CIR.0000131513.33892.5b.15198961
Fryar, CD; Te-Ching, C; Xianfen, L. (2012). Prevalence of Uncontrolled Risk Factors for Cardiovascular Disease: United States, 1999–2010. NCHS 103: 1–8.
Gaballah, S; Swank, A; Sobus, JR; Howey, XM; Schmid, J; Catron, T; Mccord, J; Hines, E; Strynar, M; Tal, T. (2020). Evaluation of developmental toxicity, developmental neurotoxicity, and tissue dose in zebrafish exposed to GenX and other PFAS. Environ Health Perspect 128: 47005. 10.1289/EHP5843.32271623
Gad, SC. (2015). Cardiovascular toxicology and its evaluation. In MB Abou-Donia (Ed.), Mammalian Toxicology. West Sussex, United Kingdom: John Wiley & Sons.
Galazka, A; Kardymowicz, B. (1989). Immunity against diphtheria in adults in Poland. Epidemiol Infect 103: 587–593. 10.1017/s0950268800030983.2514113
Galazka, AM; Milstien, JB; Robertson, SE; Cutts, FT. (1993). The immunological basis for immunization module 2 : Diphtheria. (WHO/EPI/Gen/93.11-18). Galazka, AM; Milstien, JB; Robertson, SE; Cutts, FT. http://apps.who.int/iris/bitstream/handle/10665/58891/WHO-EPI-GEN-93.12-mod2-eng.pdf?sequence=38&isAllowed=y.
Gao, K, e; Zhuang, T; Liu, X; Fu, J; Zhang, J; Fu, J, ie; Wang, L; Zhang, A; Liang, Y; Song, M; Jiang, G. (2019). Prenatal Exposure to Per- and Polyfluoroalkyl Substances (PFASs) and Association between the Placental Transfer Efficiencies and Dissociation Constant of Serum Proteins-PFAS Complexes. Environ Sci Technol 53: 6529–6538. 10.1021/acs.est.9b00715.31099564
Gao, K; Fu, J; Xue, Q; Li, Y; Liang, Y; Pan, Y; Zhang, A; Jiang, G. (2018). An integrated method for simultaneously determining 10 classes of per- and polyfluoroalkyl substances in one drop of human serum. Anal Chim Acta 999: 76–86. 10.1016/j.aca.2017.10.038.29254577
Gaylord, A; Berger, KI; Naidu, M; Attina, TM; Gilbert, J; Koshy, TT; Han, X; Marmor, M; Shao, Y; Giusti, R; Goldring, RM; Kannan, K; Trasande, L. (2019). Serum perfluoroalkyl substances and lung function in adolescents exposed to the World Trade Center disaster. Environ Res 172: 266–272. 10.1016/j.envres.2019.02.024.30822559
Gaylord, A; Trasande, L; Kannan, K; Thomas, KM; Lee, S; Liu, M; Levine, J. (2020). Persistent organic pollutant exposure and celiac disease: A pilot study. Environ Res 186: 109439. 10.1016/j.envres.2020.109439.32409013
Gelman, A; Lee, D; Guo, L. (2015). Stan: a probabilistic programming language for bayesian inference and optimization. American Educational Research Journal 40. 10.3102/1076998615606113.
Gibson, H, .M. (1973). Plasma volume and glomerular filtration rate in pregnancy and their relation to differences in fetal growth. Br J Obstet Gynaecol 80: 1067–1074. 10.1111/j.1471-0528.1973.tb02981.x.
Gleason, J, essie A. Cooper, K.,eith R. Klotz, J.,udith B. Post, G.,loria B. Van Orden, G.,eorge New Jersey Drinking Water Quality Institute (NJDWQI). (2017). Health-based maximum contaminant level support document: Perfluorooctanoic acid (PFOA): Appendix A. New Jersey Drinking Water Quality Institute (NJDWQI), Health Effects Subcommittee. https://www.state.nj.us/dep/watersupply/pdf/pfoa-appendixa.pdf.
Glynn, A; Berger, U; Bignert, A; Ullah, S; Aune, M; Lignell, S; Darnerud, PO. (2012). Perfluorinated alkyl acids in blood serum from primiparous women in Sweden: serial sampling during pregnancy and nursing, and temporal trends 1996-2010. Environ Sci Technol 46: 9071–9079. 10.1021/es301168c.22770559
Goodrich, JA; Walker, D; Lin, X; Wang, H; Lim, T; McConnell, R; Conti, DV; Chatzi, L; Setiawan, VW. (2022). Exposure to perfluoroalkyl substances and risk of hepatocellular carcinoma in a multiethnic cohort. JHEP Rep 4: 100550. 10.1016/j.jhepr.2022.100550.36111068
Gowda, S; Desai, PB; Hull, VV; Math, AAK; Vernekar, SN; Kulkarni, SS. (2009). A review on laboratory liver function tests. Pan African Medical Journal 3: 17.21532726
Grandjean, P; Andersen, EW; Budtz-Jørgensen, E; Nielsen, F; Mølbak, K; Weihe, P; Heilmann, C. (2012). Serum vaccine antibody concentrations in children exposed to perfluorinated compounds. JAMA 307: 391–397. 10.1001/jama.2011.2034.22274686
Grandjean, P; Bateson, T. (2021). RE: Benchmark analysis for PFAS immunotoxicity.
Grandjean, P; Heilmann, C; Weihe, P; Nielsen, F; Mogensen, UB; Budtz-Jørgensen, E. (2017a). Serum vaccine antibody concentrations in adolescents exposed to perfluorinated compounds. Environ Health Perspect 125: 077018. 10.1289/EHP275.28749778
Grandjean, P; Heilmann, C; Weihe, P; Nielsen, F; Mogensen, UB; Timmermann, A; Budtz-Jørgensen, E. (2017b). Estimated exposures to perfluorinated compounds in infancy predict attenuated vaccine antibody concentrations at age 5-years. J Immunotoxicol 14: 188–195. 10.1080/1547691X.2017.1360968.28805477
Gundacker, C; Audouze, K; Widhalm, R; Granitzer, S; Forsthuber, M; Jornod, F; Wielsøe, M; Long, M; Halldórsson, TI; Uhl, M; Bonefeld-Jørgensen, EC. (2022). Reduced birth weight and exposure to per- and polyfluoroalkyl substances: a review of possible underlying mechanisms using the AOP-helpFinder [Review]. Toxics 10: 684. 10.3390/toxics10110684.36422892
Guo, J; Huang, S; Yang, L; Zhou, J; Xu, X; Lin, S; Li, H; Xie, X; Wu, S. (2023). Association between polyfluoroalkyl substances exposure and sex steroids in adolescents: The mediating role of serum albumin. Ecotoxicol Environ Saf 253: 114687. 10.1016/j.ecoenv.2023.114687.36857915
Gyllenhammar, I; Benskin, JP; Sandblom, O; Berger, U; Ahrens, L; Lignell, S; Wiberg, K; Glynn, A. (2018a). Perfluoroalkyl acids (PFAAs) in serum from 2-4-month-old infants: Influence of maternal serum concentration, gestational age, breast-feeding, and contaminated drinking water. Environ Sci Technol 52: 7101–7110. 10.1021/acs.est.8b00770.29758986
Gyllenhammar, I; Diderholm, B; Gustafsson, J; Berger, U; Ridefelt, P; Benskin, JP; Lignell, S; Lampa, E; Glynn, A. (2018b). Perfluoroalkyl acid levels in first-time mothers in relation to offspring weight gain and growth. Environ Int 111: 191–199. 10.1016/j.envint.2017.12.002.29223808
Hack, M; Klein, NK; Taylor, HG. (1995). Long-term developmental outcomes of low birth weight infants [Review]. Future Child 5: 176–196. 10.2307/1602514.7543353
Hall, AP; Elcombe, CR; Foster, JR; Harada, T; Kaufmann, W; Knippel, A; Küttler, K; Malarkey, DE; Maronpot, RR; Nishikawa, A; Nolte, T; Schulte, A; Strauss, V; York, MJ. (2012). Liver hypertrophy: A review of adaptive (adverse and non-adverse) changes—Conclusions from the 3rd International ESTP Expert Workshop [Review]. Toxicol Pathol 40: 971–994. 10.1177/0192623312448935.22723046
Hallberg, I; Moberg, M; Olovsson, M; Damdimopoulou, P; Rüegg, J; Sirard, MA; Persson, S; Sjunnesson, YC. (2021). The effect of perfluorohexanesulfonate (PFHxS) on bovine preimplantation embryo development in vitro [Abstract]. Toxicol Lett 350: S169–S170. 10.1016/S0378-4274(21)00641-X.
Hallberg, I; Persson, S; Olovsson, M; Moberg, M; Ranefall, P; Laskowski, D; Damdimopoulou, P; Sirard, MA; Rüegg, J; Sjunnesson, YCB. (2022). Bovine oocyte exposure to perfluorohexane sulfonate (PFHxS) induces phenotypic, transcriptomic, and DNA methylation changes in resulting embryos in vitro. Reprod Toxicol 109: 19–30. 10.1016/j.reprotox.2022.02.004.35219833
Hamm, MP; Cherry, NM; Chan, E; Martin, JW; Burstyn, I. (2010). Maternal exposure to perfluorinated acids and fetal growth. J Expo Sci Environ Epidemiol 20: 589–597. 10.1038/jes.2009.57.19865074
Han, W; Gao, Y; Yao, Q; Yuan, T; Wang, Y; Zhao, S; Shi, R; Bonefeld-Jorgensen, EC; Shen, X; Tian, Y. (2018). Perfluoroalkyl and polyfluoroalkyl substances in matched parental and cord serum in Shandong, China. Environ Int 116: 206–213. 10.1016/j.envint.2018.04.025.29698897
Harris, MH; Oken, E; Rifas-Shiman, SL; Calafat, AM; Ye, X; Bellinger, DC; Webster, TF; White, RF; Sagiv, SK. (2018). Prenatal and childhood exposure to per- and polyfluoroalkyl substances (PFASs) and child cognition. Environ Int 115: 358–369. 10.1016/j.envint.2018.03.025.29705692
Harris, MH; Rifas-Shiman, SL; Calafat, AM; Ye, X; Mora, AM; Webster, TF; Oken, E; Sagiv, SK. (2017). Predictors of per- and polyfluoroalkyl substance (PFAS) plasma concentrations in 6-10 year old American children. Environ Sci Technol 51: 5193–5204. 10.1021/acs.est.6b05811.28325044
Haug, M; Dunder, L; Lind, PM; Lind, L; Salihovic, S. (2023). Associations of perfluoroalkyl substances (PFAS) with lipid and lipoprotein profiles. J Expo Sci Environ Epidemiol 33: 757–765. 10.1038/s41370-023-00545-x.37019983
He, A; Li, J; Li, Z; Lu, Y; Liang, Y; Zhou, Z; Man, Z; Lv, J; Wang, Y; Jiang, G. (2023). Novel insights into the adverse health effects of per- and polyfluoroalkyl substances on the kidney via human urine metabolomics. Environ Sci Technol 57: 16244–16254. 10.1021/acs.est.3c06480.37851943
He, X; Jiang, J; Zhang, XX. (2022). Environmental exposure to low-dose perfluorohexanesulfonate promotes obesity and non-alcoholic fatty liver disease in mice fed a high-fat diet. Environ Sci Pollut Res Int 29: 49279–49290. 10.1007/s11356-022-19369-7.35217953
Higgins, JPT; Thomas, J; Chandler, J; Cumpston, M; Li, T; Page, MJ; Welch, VA. (2022). Cochrane handbook for systematic reviews of interventions version 6.3. Higgins, JPT; Thomas, J; Chandler, J; Cumpston, M; Li, T; Page, MJ; Welch, VA. http://www.training.cochrane.org/handbook.
Hjermitslev, MH; Long, M; Wielsøe, M; Bonefeld-Jørgensen, EC. (2020). Persistent organic pollutants in Greenlandic pregnant women and indices of foetal growth: The ACCEPT study. Sci Total Environ 698: 134118. 10.1016/j.scitotenv.2019.134118.31494415
Højsager, FD; Andersen, M; Juul, A; Nielsen, F; Möller, S; Christensen, HT; Grøntved, A; Grandjean, P; Jensen, TK. (2022). Prenatal and early postnatal exposure to perfluoroalkyl substances and bone mineral content and density in the Odense child cohort. Environ Int 167: 107417. 10.1016/j.envint.2022.107417.35914335
Hölzer, J; Midasch, O; Rauchfuss, K; Kraft, M; Reupert, R; Angerer, J; Kleeschulte, P; Marschall, N; Wilhelm, M. (2008). Biomonitoring of perfluorinated compounds in children and adults exposed to perfluorooctanoate-contaminated drinking water. Environ Health Perspect 116: 651–657. 10.1289/ehp.11064.18470314
Hong, A; Zhuang, L; Cui, W; Lu, Q; Yang, P; Su, S; Wang, B; Zhang, G; Chen, D. (2022). Per- and polyfluoroalkyl substances (PFAS) exposure in women seeking in vitro fertilization-embryo transfer treatment (IVF-ET) in China: Blood-follicular transfer and associations with IVF-ET outcomes. Sci Total Environ 838: 156323. 10.1016/j.scitotenv.2022.156323.35636536
Hoover, G; Kar, S; Guffey, S; Leszczynski, J; Sepúlveda, MS. (2019). In vitro and in silico modeling of perfluoroalkyl substances mixture toxicity in an amphibian fibroblast cell line. Chemosphere 233: 25–33. 10.1016/j.chemosphere.2019.05.065.31163305
Hu, JMY; Arbuckle, TE; Janssen, P; Lanphear, BP; Zhuang, LH; Braun, JM; Chen, A; McCandless, LC. (2021). Prenatal exposure to endocrine disrupting chemical mixtures and infant birth weight: A Bayesian analysis using kernel machine regression. Environ Res 195: 110749. 10.1016/j.envres.2021.110749.33465343
Hu, L; Mei, H; Cai, X; Xiang, F; Li, N, a; Huang, Z; Duan, Z; Yang, P, an; Xiao, H, an. (2023). A co-twin control study of in utero exposure to poly- and perfluoroalkyl substances and associations with neonatal thyroid-stimulating hormone. Environ Res 239: 117350. 10.1016/j.envres.2023.117350.37821063
Huang, H; Wang, Q; He, X; Wu, Y; Xu, C. (2019a). Association between polyfluoroalkyl chemical concentrations and leucocyte telomere length in US adults. Sci Total Environ 653: 547–553. 10.1016/j.scitotenv.2018.10.400.30414584
Huang, H; Yu, K; Zeng, X; Chen, Q; Liu, Q; Zhao, Y; Zhang, J; Zhang, X; Huang, L. (2020). Association between prenatal exposure to perfluoroalkyl substances and respiratory tract infections in preschool children. Environ Res 191: 110156. 10.1016/j.envres.2020.110156.32871147
Huang, K; Zhou, W; Fu, J; Zhang, Q; Teng, Y; Gu, L; Fu, Y; Hu, B; Mei, Y; Zhang, H; Zhang, A; Fu, J; Jiang, G. (2023). Linking Transthyretin-Binding Chemicals and Free Thyroid Hormones: In Vitro to In Vivo Extrapolation Based on a Competitive Binding Model. Environ Sci Technol 57: 9130–9139. 10.1021/acs.est.3c01094.37261382
Huang, MC; Dzierlenga, AL; Robinson, VG; Waidyanatha, S; Devito, MJ; Eifrid, MA; Granville, CA; Gibbs, ST; Blystone, CR. (2019b). Toxicokinetics of perfluorobutane sulfonate (PFBS), perfluorohexane-1-sulphonic acid (PFHxS), and perfluorooctane sulfonic acid (PFOS) in male and female Hsd:Sprague Dawley SD rats after intravenous and gavage administration. Toxicol Rep 6: 645–655. 10.1016/j.toxrep.2019.06.016.31334035
Huedo-Medina, TB; Sánchez-Meca, J; Marín-Martínez, F; Botella, J. (2006). Assessing heterogeneity in meta-analysis: Q statistic or I2 index? Psychol Methods 11: 193–206. 10.1037/1082-989X.11.2.193.16784338
Huo, X; Huang, R; Gan, Y; Luo, K; Aimuzi, R; Nian, M; Ao, J; Feng, L; Tian, Y; Wang, W; Ye, W; Zhang, J. (2020). Perfluoroalkyl substances in early pregnancy and risk of hypertensive disorders of pregnancy: A prospective cohort study. Environ Int 138: 105656. 10.1016/j.envint.2020.105656.32222612
Hurley, S; Goldberg, D; Wang, M; Park, JS; Petreas, M; Bernstein, L; Anton-Culver, H; Nelson, DO; Reynolds, P. (2018). Breast cancer risk and serum levels of per- and poly-fluoroalkyl substances: a case-control study nested in the California Teachers Study. Environ Health 17: 83. 10.1186/s12940-018-0426-6.30482205
Hutcheson, R; Innes, K; Conway, B. (2020). Perfluoroalkyl substances and likelihood of stroke in persons with and without diabetes. Diab Vasc Dis Res 17: 1–8. 10.1177/1479164119892223.
Hvizdak, M; Kandel, SE; Work, HM; Gracey, EG; McCullough, RL; Lampe, JN. (2023). Per- and polyfluoroalkyl substances (PFAS) inhibit cytochrome P450 CYP3A7 through direct coordination to the heme iron and water displacement. J Inorg Biochem 240: 112120. 10.1016/j.jinorgbio.2023.112120.36638633
Infusino I, M, auro P. (2009). Standardization in clinical enzymology. EJIFCC 20: 141–147.27683339
IPCS (International Programme on Chemical Safety). (2007). Harmonization project document no. 4: Part 2: IPCS framework for analysing the relevance of a non-cancer mode of action for humans. Geneva, Switzerland: World Health Organization. http://www.who.int/ipcs/methods/harmonization/areas/cancermode.pdf?ua=1.
IPCS (International Programme on Chemical Safety). (2012). Guidance for immunotoxicity risk assessment for chemicals. (Harmonization Project Document No. 10). Geneva, Switzerland: World Health Organization. https://apps.who.int/iris/handle/10665/330098.
Ipsen, J. (1946). Circulating antitoxin at the onset of diphtheria in 425 patients. J Immunol 54: 325–347.20278364
Ishibashi, H; Hirano, M; Kim, EY; Iwata, H. (2019). In vitro and in silico evaluations of binding affinities of perfluoroalkyl substances to baikal seal and human peroxisome proliferator-activated receptor α. Environ Sci Technol 53: 2181–2188. 10.1021/acs.est.8b07273.30649875
Ishibashi, H; Kim, EY; Iwata, H. (2011). Transactivation potencies of the Baikal seal (Pusa sibirica) peroxisome proliferator-activated receptor α by perfluoroalkyl carboxylates and sulfonates: estimation of PFOA induction equivalency factors. Environ Sci Technol 45: 3123–3130. 10.1021/es103748s.21381677
Itoh, H; Harada, KH; Kasuga, Y; Yokoyama, S; Onuma, H; Nishimura, H; Kusama, R; Yokoyama, K; Zhu, J; Harada Sassa, M; Tsugane, S; Iwasaki, M. (2021). Serum perfluoroalkyl substances and breast cancer risk in Japanese women: A case-control study. Sci Total Environ 800: 149316. 10.1016/j.scitotenv.2021.149316.34392213
Jain, RB. (2014). Contribution of diet and other factors to the levels of selected polyfluorinated compounds: data from NHANES 2003-2008. Int J Hyg Environ Health 217: 52–61. 10.1016/j.ijheh.2013.03.008.23601780
Jain, RB; Ducatman, A. (2019). Perfluoroalkyl acids and thyroid hormones across stages of kidney function. Sci Total Environ 696: 133994. 10.1016/j.scitotenv.2019.133994.31454605
Jain, RB; Ducatman, A. (2022). Serum concentrations of selected perfluoroalkyl substances for US females compared to males as they age. Sci Total Environ 842: 156891. 10.1016/j.scitotenv.2022.156891.35753482
Jensen, RC; Glintborg, D; Timmermann, CAG; Nielsen, F; Boye, H; Madsen, JB; Bilenberg, N; Grandjean, P; Jensen, TK; Andersen, MS. (2022). Higher free thyroxine associated with PFAS exposure in first trimester. The Odense Child Cohort. Environ Res 212: 113492. 10.1016/j.envres.2022.113492.35597289
Ji, K; Kim, S; Kho, Y; Sakong, J; Paek, D; Choi, K. (2012). Major perfluoroalkyl acid (PFAA) concentrations and influence of food consumption among the general population of Daegu, Korea. Sci Total Environ 438: 42–48. 10.1016/j.scitotenv.2012.08.007.22964400
Jiang, W; Zhang, Y; Zhu, L; Deng, J. (2014). Serum levels of perfluoroalkyl acids (PFAAs) with isomer analysis and their associations with medical parameters in Chinese pregnant women. Environ Int 64: 40–47. 10.1016/j.envint.2013.12.001.24361923
Jones, RR; Madrigal, JM; Troisi, R; Surcel, HM; Öhman, H; Kivelä, J; Kiviranta, H; Rantakokko, P; Koponen, J; Medgyesi, DN; Mcglynn, KA; Sampson, J; Albert, PS; Ward, MH. (2023). Maternal serum concentrations of per- and polyfluoroalkyl substances and childhood acute lymphoblastic leukemia. J Natl Cancer Inst. 10.1093/jnci/djad261.
Joshi-Barve, S; Kirpich, I; Cave, MC; Marsano, LS; McClain, CJ. (2015). Alcoholic, nonalcoholic, and toxicant-associated steatohepatitis: Mechanistic similarities and differences [Review]. CMGH 1: 356–367. 10.1016/j.jcmgh.2015.05.006.28210688
Kalloo, G; Wellenius, GA; Mccandless, L; Calafat, AM; Sjodin, A; Romano, ME; Karagas, MR; Chen, A; Yolton, K; Lanphear, BP; Braun, JM. (2020). Exposures to chemical mixtures during pregnancy and neonatal outcomes: The HOME study. Environ Int 134: 105219. 10.1016/j.envint.2019.105219.31726361
Kang, H; Ding, N; Karvonen-Gutierrez, CA; Mukherjee, B; Calafat, AM; Park, SK. (2023). Per- and Polyfluoroalkyl Substances (PFAS) and Lipid Trajectories in Women 45-56 Years of Age: The Study of Women’s Health Across the Nation. Environ Health Perspect 131: 87004. 10.1289/EHP12351.37552133
Kashino, I; Sasaki, S; Okada, E; Matsuura, H; Goudarzi, H; Miyashita, C; Okada, E; Ito, YM; Araki, A; Kishi, R. (2020). Prenatal exposure to 11 perfluoroalkyl substances and fetal growth: A large-scale, prospective birth cohort study. Environ Int 136: 105355. 10.1016/j.envint.2019.105355.32029284
Kaur, K; Lesseur, C; Chen, L; Andra, SS; Narasimhan, S; Pulivarthi, D; Midya, V; Ma, Y; Ibroci, E; Gigase, F; Lieber, M; Lieb, W; Janevic, T; De Witte, LD; Bergink, V; Rommel, AS; Chen, J. (2023). Cross-sectional associations of maternal PFAS exposure on SARS-CoV-2 IgG antibody levels during pregnancy. Environ Res 219: 115067. 10.1016/j.envres.2022.115067.36528042
Kavlock, RJ; Allen, BC; Faustman, EM; Kimmel, CA. (1995). Dose-response assessments for developmental toxicity. IV. Benchmark doses for fetal weight changes. Toxicol Sci 26: 211–222. 10.1006/faat.1995.1092.
Kim, JH; Park, HY; Jeon, JD; Kho, Y; Kim, SK; Park, MS; Hong, YC. (2015). The modifying effect of vitamin C on the association between perfluorinated compounds and insulin resistance in the Korean elderly: a double-blind, randomized, placebo-controlled crossover trial. Eur J Nutr 55: 1011–1020. 10.1007/s00394-015-0915-0.25939797
Kim, JI; Kim, BN; Lee, YA; Shin, CH; Hong, YC; Døssing, LD; Hildebrandt, G; Lim, YH. (2023a). Association between early-childhood exposure to perfluoroalkyl substances and ADHD symptoms: A prospective cohort study. Sci Total Environ 879: 163081. 10.1016/j.scitotenv.2023.163081.36972880
Kim, K; Bennett, DH; Calafat, AM; Hertz-Picciotto, I; Shin, HM. (2020). Temporal trends and determinants of serum concentrations of per- and polyfluoroalkyl substances among Northern California mothers with a young child, 2009-2016. Environ Res 186: 109491. 10.1016/j.envres.2020.109491.32361076
Kim, MJ; Moon, S; Oh, BC; Jung, D; Ji, K; Choi, K; Park, YJ. (2018a). Association between perfluoroalkyl substances exposure and thyroid function in adults: A meta-analysis. PLoS ONE 13: e0197244. 10.1371/journal.pone.0197244.29746532
Kim, OJ; Kim, S; Park, EY; Oh, JK; Jung, SK; Park, S; Hong, S; Jeon, HL; Kim, HJ; Park, B; Park, B; Kim, S; Kim, B. (2023b). Exposure to serum perfluoroalkyl substances and biomarkers of liver function: The Korean national environmental health survey 2015-2017. Chemosphere 322: 138208. 10.1016/j.chemosphere.2023.138208.36822523
Kim, SJ; Heo, SH; Lee, DS; Hwang, IG; Lee, YB; Cho, HY. (2016). Gender differences in pharmacokinetics and tissue distribution of 3 perfluoroalkyl and polyfluoroalkyl substances in rats. Food Chem Toxicol 97: 243–255. 10.1016/j.fct.2016.09.017.27637925
Kim, SJ; Shin, H; Lee, YB; Cho, HY. (2018b). Sex-specific risk assessment of PFHxS using a physiologically based pharmacokinetic model. Arch Toxicol 92: 1113–1131. 10.1007/s00204-017-2116-5.29143853
Koponen, J; Winkens, K; Airaksinen, R; Berger, U; Vestergren, R; Cousins, IT; Karvonen, AM; Pekkanen, J; Kiviranta, H. (2018). Longitudinal trends of per- and polyfluoroalkyl substances in children’s serum. Environ Int 121: 591–599. 10.1016/j.envint.2018.09.006.30308470
Korevaar, TIM; Muetzel, R; Medici, M; Chaker, L; Jaddoe, VWV; de Rijke, YB; Steegers, EAP; Visser, TJ; White, T; Tiemeier, H; Peeters, RP. (2016). Association of maternal thyroid function during early pregnancy with offspring IQ and brain morphology in childhood: A population-based prospective cohort study. Lancet Diabetes Endocrinol 4: 35–43. 10.1016/S2213-8587(15)00327-7.26497402
Kruschke, JK. (2021). Bayesian analysis reporting guidelines. Nat Hum Behav 5: 1282–1291. 10.1038/s41562-021-01177-7.34400814
Kwon, EJ; Shin, JS; Kim, BM; Shah-Kulkarni, S; Park, H; Kho, YL; Park, EA; Kim, YJ; Ha, EH. (2016). Prenatal exposure to perfluorinated compounds affects birth weight through GSTM1 polymorphism. J Occup Environ Med 58: e198–e205. 10.1097/JOM.0000000000000739.27206125
Larsen, A. (2022). R markdown code for the meta-analysis of PFHxS on birthweight [Computer Program].
Leary, DB; Takazawa, M; Kannan, K; Khalil, N. (2020). Perfluoroalkyl substances and metabolic syndrome in firefighters a pilot study. J Occup Environ Med 62: 52–57. 10.1097/JOM.0000000000001756.31658221
Leclercq, A; Ranefall, P; Sjunnesson, YCB; Hallberg, I. (2022). Occurrence of late-apoptotic symptoms in porcine preimplantation embryos upon exposure of oocytes to perfluoroalkyl substances (PFASs) under in vitro meiotic maturation. PLoS ONE 17: e0279551. 10.1371/journal.pone.0279551.36576940
Lee, E; Kinninger, A; Ursin, G; Tseng, C; Hurley, S; Wang, M; Wang, Y; Park, JS; Petreas, M; Deapen, D; Reynolds, P. (2020). Serum levels of commonly detected persistent organic pollutants and per- and polyfluoroalkyl substances (PFASs) and mammographic density in postmenopausal women. Int J Environ Res Public Health 17: 606. 10.3390/ijerph17020606.31963577
Lee, I; Viberg, H. (2013). A single neonatal exposure to perfluorohexane sulfonate (PFHxS) affects the levels of important neuroproteins in the developing mouse brain. Neurotoxicology 37: 190–196. 10.1016/j.neuro.2013.05.007.23701969
Lenters, V; Portengen, L; Rignell-Hydbom, A; Jönsson, BA; Lindh, CH; Piersma, AH; Toft, G; Bonde, JP; Heederik, D; Rylander, L; Vermeulen, R. (2016). Prenatal phthalate, perfluoroalkyl acid, and organochlorine exposures and term birth weight in three birth cohorts: multi-pollutant models based on elastic net regression. Environ Health Perspect 124: 365–372. 10.1289/ehp.1408933.26115335
Lewin, A; Arbuckle, TE; Fisher, M; Liang, CL; Marro, L; Davis, K; Abdelouahab, N; Fraser, WD. (2017). Univariate predictors of maternal concentrations of environmental chemicals: The MIREC study. Int J Hyg Environ Health 220: 77–85. 10.1016/j.ijheh.2017.01.001.28109710
Li, A; Hou, J; Fu, J; Wang, Y; Hu, Y; Zhuang, T; Li, M; Song, M; Jiang, G. (2023a). Association between serum levels of TSH and free T4 and per- and polyfluoroalkyl compounds concentrations in pregnant women. J Environ Sci 124: 11–18. 10.1016/j.jes.2021.10.026.
Li, B; Bao, Y; Xu, Y; Xie, S; Huang, J. (2017a). Vertical distribution of microbial communities in soils contaminated by chromium and perfluoroalkyl substances. Sci Total Environ 599–600: 156–164. 10.1016/j.scitotenv.2017.04.241.
Li, H; Chen, J; Jingchao, L; Yang, J; Tan, Z; Li, L; Xiao, F; An, Z; Ma, C; Liu, Y; Wang, L; Zhang, X; Guo, H. (2023b). Association of exposure to perfluoroalkyl substances and risk of the acute coronary syndrome: A case-control study in Shijiazhuang Hebei Province. Chemosphere 313: 137464. 10.1016/j.chemosphere.2022.137464.36495974
Li, H; Hammarstrand, S; Midberg, B; Xu, Y; Li, Y; Olsson, DS; Fletcher, T; Jakobsson, K; Andersson, EM. (2022a). Cancer incidence in a Swedish cohort with high exposure to perfluoroalkyl substances in drinking water. Environ Res 204: 112217. 10.1016/j.envres.2021.112217.34662573
Li, H; Yang, M; Yang, J; Seery, S; Ma, C; Liu, Y; Zhang, X; Li, A; Guo, H. (2023c). Per- and polyfluoroalkyl substances and the associated thyroid cancer risk: A case-control study in China. Chemosphere 337: 139411. 10.1016/j.chemosphere.2023.139411.37419160
Li, J; Yang, L; He, G; Wang, B; Miao, M; Ji, H; Wen, S; Cao, W; Yuan, W; Liang, H. (2022b). Association between prenatal exposure to perfluoroalkyl substances and anogenital distance in female neonates. Ecotoxicol Environ Saf 245: 114130. 10.1016/j.ecoenv.2022.114130.36182800
Li, J; Yao, J; Xia, W; Dai, J; Liu, H; Pan, Y; Xu, S; Lu, S; Jin, S; Li, Y; Sun, X; Zhang, B; Zheng, T; Jiang, Y; Jing, T. (2020). Association between exposure to per- and polyfluoroalkyl substances and blood glucose in pregnant women. Int J Hyg Environ Health 230: 113596. 10.1016/j.ijheh.2020.113596.32896786
Li, K; Gao, P; Xiang, P; Zhang, X; Cui, X; Ma, LQ. (2017b). Molecular mechanisms of PFOA-induced toxicity in animals and humans: Implications for health risks [Review]. Environ Int 99: 43–54. 10.1016/j.envint.2016.11.014.27871799
Li, M; Zeng, XW; Qian, ZM; Vaughn, MG; Sauvé, S; Paul, G; Lin, S; Lu, L; Hu, LW; Yang, BY; Zhou, Y; Qin, XD; Xu, SL; Bao, WW; Zhang, YZ; Yuan, P; Wang, J; Zhang, C; Tian, YP; Nian, M; Xiao, X; Fu, C; Dong, GH. (2017c). Isomers of perfluorooctanesulfonate (PFOS) in cord serum and birth outcomes in China: Guangzhou Birth Cohort Study. Environ Int 102: 1–8. 10.1016/j.envint.2017.03.006.28297681
Li, QQ; Huang, J; Cai, D; Chou, WC; Zeeshan, M; Chu, C; Zhou, Y; Lin, L; Ma, HM; Tang, C; Kong, M; Xie, Y; Dong, GH; Zeng, XW. (2023d). Prenatal exposure to legacy and alternative per- and polyfluoroalkyl substances and neuropsychological development trajectories over the first 3 years of life. Environ Sci Technol 57: 3746–3757. 10.1021/acs.est.2c07807.36800558
Li, S; Cirillo, P; Hu, X; Tran, V; Krigbaum, N; Yu, S; Jones, DP; Cohn, B. (2019). Understanding mixed environmental exposures using metabolomics via a hierarchical community network model in a cohort of California women in 1960’s. Reprod Toxicol 92: 57–65. 10.1016/j.reprotox.2019.06.013.31299210
Li, X; Song, F; Liu, X; Shan, A; Huang, Y; Yang, Z; Li, H; Yang, Q; Yu, Y; Zheng, H; Cao, XC; Chen, D; Chen, KX; Chen, X; Tang, NJ. (2022c). Perfluoroalkyl substances (PFASs) as risk factors for breast cancer: a case-control study in Chinese population. Environ Health 21: 83. 10.1186/s12940-022-00895-3.36085159
Li, Y; Andersson, A; Xu, Y; Pineda, D; Nilsson, CA; Lindh, CH; Jakobsson, K; Fletcher, T. (2022d). Determinants of serum half-lives for linear and branched perfluoroalkyl substances after long-term high exposure—A study in Ronneby, Sweden. Environ Int 163: 107198. 10.1016/j.envint.2022.107198.35447437
Liang, JL; Tiwari, T; Moro, P; Messonnier, NE; Reingold, A; Sawyer, M; Clark, TA. (2018). Prevention of pertussis, tetanus, and diphtheria with vaccines in the United States: Recommendations of the Advisory Committee on Immunization Practices (ACIP). MMWR Recomm Rep 67: 1–44. 10.15585/mmwr.rr6702a1.
Liang, Y; Zhou, H; Zhang, J; Li, S; Shen, W; Lei, L. (2023). Exposure to perfluoroalkyl and polyfluoroalkyl substances and estimated glomerular filtration rate in adults: a cross-sectional study based on NHANES (2017-2018). Environ Sci Pollut Res Int 30: 57931–57944. 10.1007/s11356-023-26384-9.36971931
Liao, Q; Tang, P; Fan, H; Song, Y; Liang, J; Huang, H; Pan, D; Mo, M; Leilei; Lin, M; Chen, J; Wei, H; Long, J; Shao, Y; Zeng, X; Liu, S; Huang, D; Qiu, X. (2023). Association between maternal exposure to per- and polyfluoroalkyl substances and serum markers of liver function during pregnancy in China: A mixture-based approach. Environ Pollut 323: 121348. 10.1016/j.envpol.2023.121348.36842621
Liao, Q; Tang, P; Pan, D; Song, Y; Lei, L; Liang, J; Liu, B; Lin, M; Huang, H; Mo, M; Huang, C; Wei, M; Liu, S; Huang, D; Qiu, X. (2022a). Association of serum per- and polyfluoroalkyl substances and gestational anemia during different trimesters in Zhuang ethnic pregnancy women of Guangxi, China. Chemosphere 309: 136798. 10.1016/j.chemosphere.2022.136798.36220436
Liao, Q; Tang, P; Song, Y; Liu, B; Huang, H; Liang, J; Lin, M; Shao, Y; Liu, S; Pan, D; Huang, D; Qiu, X. (2022b). Association of single and multiple prefluoroalkyl substances exposure with preterm birth: Results from a Chinese birth cohort study. Chemosphere 307: 135741. 10.1016/j.chemosphere.2022.135741.35863418
Liew, Z; Luo, J; Nohr, EA; Bech, BH; Bossi, R; Arah, OA; Olsen, J. (2020). Maternal plasma perfluoroalkyl substances and miscarriage: a nested case-control study in the Danish National Birth Cohort. Environ Health Perspect 128: 47007. 10.1289/EHP6202.32319790
Liew, Z; Ritz, B; Bonefeld-Jørgensen, EC; Henriksen, TB; Nohr, EA; Bech, BH; Fei, C; Bossi, R; von Ehrenstein, OS; Streja, E; Uldall, P; Olsen, J. (2014). Prenatal exposure to perfluoroalkyl substances and the risk of congenital cerebral palsy in children. Am J Epidemiol 180: 574–581. 10.1093/aje/kwu179.25139206
Limei, E; Zhang, S; Jiang, X. (2023). Association between perfluoroalkyl substances exposure and the prevalence of nonalcoholic fatty liver disease in the different sexes: a study from the National Health and Nutrition Examination Survey 2005-2018. Environ Sci Pollut Res Int 30: 44292–44303. 10.1007/s11356-023-25258-4.36692718
Limpert, E; Stahel, WA; Abbt, M. (2001). Log-normal Distributions across the Sciences: Keys and Clues: On the charms of statistics, and how mechanical models resembling gambling machines offer a link to a handy way to characterize log-normal distributions, which can provide deeper insight into variability and probability—normal or log-normal: That is the question. Bioscience 51: 341–352. 10.1641/0006-3568(2001)051[0341:LNDATS]2.0.CO;2.
Lin, HW; Feng, HX; Chen, L; Yuan, XJ; Tan, Z. (2020). Maternal exposure to environmental endocrine disruptors during pregnancy is associated with pediatric germ cell tumors. Nagoya J Med Sci 82: 323–333. 10.18999/nagjms.82.2.323.32581411
Lin, M; Liao, Q; Tang, P; Song, Y; Liang, J, un; Li, J; Mu, C; Liu, S; Qiu, X; Yi, R, ui; Pang, Q; Pan, D; Zeng, X; Huang, D. (2022). Association of maternal perfluoroalkyl substance exposure with postpartum haemorrhage in Guangxi, China. Ecotoxicol Environ Saf 245: 114078. 10.1016/j.ecoenv.2022.114078.36137419
Linakis, MW; Landingham, CW; Gasparini, A; Longnecker, MP. (2021). Re-expressing coefficients from regression models for inclusion in a meta-analysis. Linakis, MW; Landingham, CW; Gasparini, A; Longnecker, MP. 10.1101/2021.11.02.466931.
Lind, DV; Priskorn, L; Lassen, TH; Nielsen, F; Kyhl, HB; Kristensen, DM; Christesen, HT; Jørgensen, JS; Grandjean, P; Jensen, TK. (2017). Prenatal exposure to perfluoroalkyl substances and anogenital distance at 3 months of age in a Danish mother-child cohort. Reprod Toxicol 68: 200–206. 10.1016/j.reprotox.2016.08.019.27592399
Lind, PM; Salihovic, S; Stubleski, J; Kärrman, A; Lind, L. (2018). Changes in plasma levels of perfluoroalkyl substances (PFASs) are related to increase in carotid intima-media thickness over 10 years - a longitudinal study. Environ Health 17: 59. 10.1186/s12940-018-0403-0.29970113
Liu, H; Pan, Y; Jin, S; Sun, X; Jiang, Y; Wang, Y; Ghassabian, A; Li, Y; Xia, W; Cui, Q; Zhang, B; Zhou, A; Dai, J; Xu, S. (2020a). Associations between six common per- and polyfluoroalkyl substances and estrogens in neonates of China. J Hazard Mater 407: 124378. 10.1016/j.jhazmat.2020.124378.33139105
Liu, J; Gao, X; Wang, Y; Leng, J; Li, J; Zhao, Y; Wu, Y. (2020b). Profiling of emerging and legacy per- /polyfluoroalkyl substances in serum among pregnant women in China. Environ Pollut 271: 116376. 10.1016/j.envpol.2020.116376.33383424
Liu, S; Yang, R; Yin, N; Faiola, F. (2020c). Effects of per- and poly-fluorinated alkyl substances on pancreatic and endocrine differentiation of human pluripotent stem cells. Chemosphere 254: 126709. 10.1016/j.chemosphere.2020.126709.32348926
Liu, S; Yang, R; Yin, N; Faiola, F. (2020d). The short-chain perfluorinated compounds PFBS, PFHxS, PFBA and PFHxA, disrupt human mesenchymal stem cell self-renewal and adipogenic differentiation. J Environ Sci 88: 187–199. 10.1016/j.jes.2019.08.016.
Liu, X; Zhang, L; Chen, L; Li, J; Wang, Y; Wang, J; Meng, G; Chi, M; Zhao, Y; Chen, H; Wu, Y. (2019). Structure-based investigation on the association between perfluoroalkyl acids exposure and both gestational diabetes mellitus and glucose homeostasis in pregnant women. Environ Int 127: 85–93. 10.1016/j.envint.2019.03.035.30909097
Liu, Y; Li, N; Papandonatos, GD; Calafat, AM; Eaton, CB; Kelsey, KT; Chen, A; Lanphear, BP; Cecil, KM; Kalkwarf, HJ; Yolton, K; Braun, JM. (2020e). Exposure to per- and polyfluoroalkyl substances and adiposity at age 12 years: Evaluating periods of susceptibility. Environ Sci Technol 54: 16039–16049. 10.1021/acs.est.0c06088.33269902
Liu, Y; Zhang, Z; Han, D; Zhao, Y; Yan, X; Cui, S. (2022). Association between environmental chemicals co-exposure and peripheral blood immune-inflammatory indicators. Front Public Health 10: 980987. 10.3389/fpubh.2022.980987.36483254
Luo, D; Wu, WX; Pan, YA; Du, BB; Shen, MJ; Zeng, LX. (2021). Associations of prenatal exposure to per- and polyfluoroalkyl substances with the neonatal birth size and hormones in the growth hormone/insulin-like growth factor axis. Environ Sci Technol 55: 11859–11873. 10.1021/acs.est.1c02670.34378915
Luo, F; Chen, Q; Yu, G; Huo, X; Wang, H; Nian, M; Tian, Y; Xu, J; Zhang, J; Zhang, J. (2022a). Exposure to perfluoroalkyl substances and neurodevelopment in 2-year-old children: A prospective cohort study. Environ Int 166: 107384. 10.1016/j.envint.2022.107384.35834943
Luo, K; Huang, W; Zhang, Q; Liu, X; Nian, M; Wei, M; Wang, Y; Chen, D; Chen, X; Zhang, J. (2022b). Environmental exposure to legacy poly/perfluoroalkyl substances, emerging alternatives and isomers and semen quality in men: A mixture analysis. Sci Total Environ 833: 155158. 10.1016/j.scitotenv.2022.155158.35421474
Luo, K; Liu, X; Zhou, W; Nian, M; Qiu, W; Yang, Y; Zhang, J. (2022c). Preconception exposure to perfluoroalkyl and polyfluoroalkyl substances and couple fecundity: A couple-based exploration. Environ Int 170: 107567. 10.1016/j.envint.2022.107567.36240624
Luster, MI; Johnson, VJ; Yucesoy, B; Simeonova, PP. (2005). Biomarkers to assess potential developmental immunotoxicity in children. Toxicol Appl Pharmacol 206: 229–236. 10.1016/j.taap.2005.02.010.15967213
Lynch, MT; Lay, CR; Sokolinski, S; Antezana, A; Ghio, C; Chiu, WA; Rogers, R. (2023). Community-facing toxicokinetic models to estimate PFAS serum levels based on life history and drinking water exposures. Environ Int 176: 107974. 10.1016/j.envint.2023.107974.37245445
Ma, S; Xu, C; Ma, J; Wang, Z; Zhang, Y; Shu, Y; Mo, X. (2019). Association between perfluoroalkyl substance concentrations and blood pressure in adolescents. Environ Pollut 254: 112971. 10.1016/j.envpol.2019.112971.31394346
Ma, X; Cui, L; Chen, L; Zhang, J; Zhang, X; Kang, Q; Jin, F; Ye, Y. (2021). Parental plasma concentrations of perfluoroalkyl substances and In Vitro fertilization outcomes. Environ Pollut 269: 116159. 10.1016/j.envpol.2020.116159.33279270
Madrigal, JM; Troisi, R; Surcel, HM; Öhman, H; Kivelä, J; Kiviranta, H; Rantakokko, P; Koponen, J; Medgyesi, DN; Kitahara, CM; McGlynn, KA; Sampson, J; Albert, PS; Ward, MH; Jones, RR. (2024). Prediagnostic serum concentrations of per- and polyfluoroalkyl substances and risk of papillary thyroid cancer in the Finnish Maternity Cohort. Int J Cancer 154: 979–991. 10.1002/ijc.34776.37902275
Maekawa, R; Ito, R; Iwasaki, Y; Saito, K; Akutsu, K; Takatori, S; Ishii, R; Kondo, F; Arai, Y; Ohgane, J; Shiota, K; Makino, T; Sugino, N. (2017). Evidence of exposure to chemicals and heavy metals during pregnancy in Japanese women. Reproductive Medicine and Biology 16: 337–348. 10.1002/rmb2.12049.29259487
Maisonet, M; Terrell, ML; Mcgeehin, MA; Christensen, KY; Holmes, A; Calafat, AM; Marcus, M. (2012). Maternal concentrations of polyfluoroalkyl compounds during pregnancy and fetal and postnatal growth in British girls. Environ Health Perspect 120: 1432–1437. 10.1289/ehp.1003096.22935244
Mann, MM; Tang, JD; Berger, BW. (2021). Engineering human liver fatty acid binding protein for detection of poly- and perfluoroalkyl substances. Biotechnol Bioeng 119: 513–522. 10.1002/bit.27981.34723386
Manzano-Salgado, C. (2022). Email correspondence with study author, Cyntia Manzano-Salgado.
Manzano-Salgado, CB; Casas, M; Lopez-Espinosa, MJ; Ballester, F; Iñiguez, C; Martinez, D; Costa, O; Santa-Marina, L; Pereda-Pereda, E; Schettgen, T; Sunyer, J; Vrijheid, M. (2017). Prenatal exposure to perfluoroalkyl substances and birth outcomes in a Spanish birth cohort. Environ Int 108: 278–284. 10.1016/j.envint.2017.09.006.28917208
Manzano-Salgado, CB; Granum, B; Lopez-Espinosa, MJ; Ballester, F; Iñiguez, C; Gascón, M; Martínez, D; Guxens, M; Basterretxea, M; Zabaleta, C; Schettgen, T; Sunyer, J; Vrijheid, M; Casas, M. (2019). Prenatal exposure to perfluoroalkyl substances, immune-related outcomes, and lung function in children from a Spanish birth cohort study. Int J Hyg Environ Health 222: 945–954. 10.1016/j.ijheh.2019.06.005.31262703
Marks, KJ; Cutler, AJ; Jeddy, Z; Northstone, K; Kato, K; Hartman, TJ. (2019a). Maternal serum concentrations of perfluoroalkyl substances and birth size in British boys. Int J Hyg Environ Health 222: 889–895. 10.1016/j.ijheh.2019.03.008.30975573
Marks, KJ; Jeddy, Z; Flanders, WD; Northstone, K; Fraser, A; Calafat, AM; Kato, K; Hartman, TJ. (2019b). Maternal serum concentrations of perfluoroalkyl substances during pregnancy and gestational weight gain: The Avon Longitudinal Study of Parents and Children. Reprod Toxicol 90: 8–14. 10.1016/j.reprotox.2019.08.003.31415809
Marques, ES; Agudelo, J; Kaye, EM; Modaresi, SMS; Pfohl, M; Bečanová, J; Wei, W; Polunas, M; Goedken, M; Slitt, AL. (2021). The role of maternal high fat diet on mouse pup metabolic endpoints following perinatal PFAS and PFAS mixture exposure. Toxicology 462: 152921. 10.1016/j.tox.2021.152921.34464680
Meek, ME; Boobis, A; Cote, I; Dellarco, V; Fotakis, G; Munn, S; Seed, J; Vickers, C. (2014). New developments in the evolution and application of the WHO/IPCS framework on mode of action/species concordance analysis [Review]. J Appl Toxicol 34: 1–18. 10.1002/jat.2949.24166207
Mehta, SS; Applebaum, KM; James-Todd, T; Coleman-Phox, K; Adler, N; Laraia, B; Epel, E; Parry, E; Wang, M; Park, JS; Zota, AR. (2020). Associations between sociodemographic characteristics and exposures to PBDEs, OH-PBDEs, PCBs, and PFASs in a diverse, overweight population of pregnant women. J Expo Sci Environ Epidemiol 30: 42–55. 10.1038/s41370-019-0173-y.31548625
Mehta, SS; James-Todd, T; Applebaum, KM; Bellavia, A; Coleman-Phox, K; Adler, N; Laraia, B; Epel, E; Parry, E; Wang, M; Park, JS; Zota, AR. (2021). Persistent organic pollutants and maternal glycemic outcomes in a diverse pregnancy cohort of overweight women. Environ Res 193: 110551. 10.1016/j.envres.2020.110551.33278474
Mellor, CL; Steinmetz, FP; Cronin, MT. (2016). The identification of nuclear receptors associated with hepatic steatosis to develop and extend adverse outcome pathways [Review]. Crit Rev Toxicol 46: 138–152. 10.3109/10408444.2015.1089471.26451809
Meng, Q; Inoue, K; Ritz, B; Olsen, J; Liew, Z. (2018). Prenatal exposure to perfluoroalkyl substances and birth outcomes; An updated analysis from the Danish national birth cohort. Int J Environ Res Public Health 15: 1832. 10.3390/ijerph15091832.30149566
Menger, F; Pohl, J; Ahrens, L; Carlsson, G; Örn, S. (2020). Behavioural effects and bioconcentration of per- and polyfluoroalkyl substances (PFASs) in zebrafish (Danio rerio) embryos. Chemosphere 245: 125573. 10.1016/j.chemosphere.2019.125573.31877453
Mitro, SD; Sagiv, SK; Fleisch, AF; Jaacks, LM; Williams, PL; Rifas-Shiman, SL; Calafat, AM; Hivert, MF; Oken, E; James-Todd, TM. (2020a). Pregnancy per- and polyfluoroalkyl substance concentrations and postpartum health in project viva: A prospective cohort. J Clin Endocrinol Metab 105: e3415–e3426. 10.1210/clinem/dgaa431.32620010
Mitro, SD; Sagiv, SK; Rifas-Shiman, SL; Calafat, AM; Fleisch, AF; Jaacks, LM; Williams, PL; Oken, E; James-Todd, TM. (2020b). Per- and polyfluoroalkyl substance exposure, gestational weight gain, and postpartum weight changes in Project Viva. Obesity (Silver Spring) 28: 1984–1992. 10.1002/oby.22933.32959518
Mitro, SD; Sundaram, R; Buck Louis, GM; Peddada, S; Chen, Z; Kannan, K; Gleason, JL; Zhang, C; Grantz, KL. (2023). Associations of Pregnancy Per- and Polyfluoroalkyl Substance Concentrations and Uterine Fibroid Changes across Pregnancy: NICHD Fetal Growth Studies - Singletons Cohort. Environ Health Perspect 131: 57007. 10.1289/EHP11606.37224071
Modaresi, SMS; Wei, W; Emily, M; DaSilva, NA; Slitt, AL. (2021). Per- and polyfluoroalkyl substances (PFAS) augment adipogenesis and shift the proteome in murine 3T3-L1 adipocytes. Toxicology 465: 153044. 10.1016/j.tox.2021.153044.34800597
Mogensen, UB; Grandjean, P; Heilmann, C; Nielsen, F; Weihe, P; Budtz-Jørgensen, E. (2015). Structural equation modeling of immunotoxicity associated with exposure to perfluorinated alkylates. Environ Health 14: 47. 10.1186/s12940-015-0032-9.26041029
Monroy, R; Morrison, K; Teo, K; Atkinson, S; Kubwabo, C; Stewart, B; Foster, WG. (2008). Serum levels of perfluoroalkyl compounds in human maternal and umbilical cord blood samples. Environ Res 108: 56–62. 10.1016/j.envres.2008.06.001.18649879
Moon, J; Mun, Y. (2024). The association between per- and polyfluoroalkyl substances (PFASs) and brain, esophageal, melanomatous skin, prostate, and lung cancer using the 2003-2018 US National Health and Nutrition Examination Survey (NHANES) datasets. Heliyon 10: e24337. 10.1016/j.heliyon.2024.e24337.38298650
Morgan, S; Mottaleb, MA; Kraemer, MP; Moser, DK; Worley, J; Morris, AJ; Petriello, MC. (2023). Effect of lifestyle-based lipid lowering interventions on the relationship between circulating levels of per-and polyfluoroalkyl substances and serum cholesterol. Environ Toxicol Pharmacol 98: 104062. 10.1016/j.etap.2023.104062.36621559
Morken, NH; Travlos, GS; Wilson, RE; Eggesbø, M; Longnecker, MP. (2014). Maternal glomerular filtration rate in pregnancy and fetal size. PLoS ONE 9: e101897. 10.1371/journal.pone.0101897.25003331
Mwapasa, M; Huber, S; Chakhame, BM; Maluwa, A; Odland, ML; Rollin, H; Choko, A; Xu, S; Odland, JO. (2023). Serum Concentrations of Selected Poly- and Perfluoroalkyl Substances (PFASs) in Pregnant Women and Associations with Birth Outcomes. A Cross-Sectional Study from Southern Malawi. Int J Environ Res Public Health 20: 1689. 10.3390/ijerph20031689.36767049
Nair, AS; Ma, ZQ; Watkins, SM; Wood, SS. (2021). Demographic and exposure characteristics as predictors of serum per- and polyfluoroalkyl substances (PFASs) levels - A community-level biomonitoring project in Pennsylvania. Int J Hyg Environ Health 231: 113631. 10.1016/j.ijheh.2020.113631.33035738
Narizzano, AM; Bohannon, ME; East, AG; Guigni, BA; Quinn, MJ. (2023). Reproductive and immune effects emerge at similar thresholds of PFHxS in deer mice. Reprod Toxicol 120: 108421. 10.1016/j.reprotox.2023.108421.37330177
Nguyen, GTH; Nocentini, A; Angeli, A; Gratteri, P; Supuran, CT; Donald, WA. (2020). Perfluoroalkyl substances of significant environmental concern can strongly inhibit human carbonic anhydrase isozymes. Anal Chem 92: 4614–4622. 10.1021/acs.analchem.0c00163.32096628
Nian, M; Huo, X; Zhang, J; Mao, Y; Jin, F; Shi, Y; Zhang, J. (2022). Association of emerging and legacy per- and polyfluoroalkyl substances with unexplained recurrent spontaneous abortion. Ecotoxicol Environ Saf 239: 113691. 10.1016/j.ecoenv.2022.113691.35643033
Nian, M; Luo, K; Luo, F; Aimuzi, R; Huo, X; Chen, Q; Tian, Y; Zhang, J. (2020). Association between prenatal exposure to PFAS and fetal sex hormones: Are the short-chain PFAS safer? Environ Sci Technol 54: 8291–8299. 10.1021/acs.est.0c02444.32525661
Nilsson, S; Smurthwaite, K; Aylward, LL; Kay, M; Toms, LM; King, L; Marrington, S; Barnes, C; Kirk, MD; Mueller, JF; Bräunig, J. (2022a). Serum concentration trends and apparent half-lives of per- and polyfluoroalkyl substances (PFAS) in Australian firefighters. Int J Hyg Environ Health 246: 114040. 10.1016/j.ijheh.2022.114040.36162311
Nilsson, S; Smurthwaite, K; Aylward, LL; Kay, M; Toms, LM; King, L; Marrington, S; Kirk, MD; Mueller, JF; Bräunig, J. (2022b). Associations between serum perfluoroalkyl acid (PFAA) concentrations and health related biomarkers in firefighters. Environ Res 215: 114370. 10.1016/j.envres.2022.114370.36174755
NJDWQI (New Jersey Drinking Water Quality Institute). (2017). Public review draft: Health-based maximum contaminant level support document: Perfluorooctane sulfonate (PFOS) (CAS #: 1763-23-1; Chemical Formula: C8HF17O3S). NJDWQI Health Effects Subcommittee. https://cswab.org/wp-content/uploads/2018/09/New-Jersey-Scientific-Documentation-Supporting-PFOS-13-ppt.pdf.
NTP (National Toxicology Program). (2018). 28-day evaluation of the toxicity (C06100) of perfluorohexane sulfonate potassium salt (PFHSKslt) (3871-99-6) on Harlan Sprague-Dawley rats exposed via gavage. Available online at 10.22427/NTP-DATA-002-03267-0002-0000-2 (accessed October 13, 2020).
NTP (National Toxicology Program). (2019). NTP technical report on the toxicity studies of perfluoroalkyl sulfonates (perfluorobutane sulfonic acid, perfluorohexane sulfonate potassium salt, and perfluorooctane sulfonic acid) administered by gavage to Sprague Dawley (Hsd:Sprague Dawley SD) rats. (Toxicity Report 96). Research Triangle Park, NC. https://ntp.niehs.nih.gov/ntp/htdocs/strpts/tox096508.pdf.
Oh, J; Bennett, DH; Tancredi, DJ; Calafat, AM; Schmidt, RJ; Hertz-Picciotto, I; Shin, HM. (2022a). Longitudinal Changes in Maternal Serum Concentrations of Per- and Polyfluoroalkyl Substances from Pregnancy to Two Years Postpartum. Environ Sci Technol 56: 11449–11459. 10.1021/acs.est.1c07970.35904360
Oh, J; Shin, HM; Kannan, K; Busgang, SA; Schmidt, RJ; Schweitzer, JB; Hertz-Picciotto, I; Bennett, DH. (2022b). Childhood exposure to per- and polyfluoroalkyl substances and neurodevelopment in the CHARGE case-control study. Environ Res 215: 114322. 10.1016/j.envres.2022.114322.36108719
Ojo, AF; Peng, C; Ng, JC. (2020). Combined effects and toxicological interactions of perfluoroalkyl and polyfluoroalkyl substances mixtures in human liver cells (HepG2). Environ Pollut 263: 114182. 10.1016/j.envpol.2020.114182.32247900
Ojo, AF; Xia, Q; Peng, C; Ng, JC. (2021). Evaluation of the individual and combined toxicity of perfluoroalkyl substances to human liver cells using biomarkers of oxidative stress. Chemosphere 281: 130808. 10.1016/j.chemosphere.2021.130808.34022600
Ouidir, M; Buck Louis, GM; Kanner, J; Grantz, KL; Zhang, C; Sundaram, R; Rahman, ML; Lee, S; Kannan, K; Tekola-Ayele, F; Mendola, P. (2020). Association of maternal exposure to persistent organic pollutants in early pregnancy with fetal growth. JAMA Pediatr 174: 149–161. 10.1001/jamapediatrics.2019.5104.31886849
Oulhote, Y; Coull, B; Bind, MA; Debes, F; Nielsen, F; Tamayo, I; Weihe, P; Grandjean, P. (2019). Joint and independent neurotoxic effects of early life exposures to a chemical mixture: A multi-pollutant approach combining ensemble learning and g-computation. Environmental Epidemiology 3: e063. 10.1097/ee9.0000000000000063.32051926
Pacifico, L; Ferraro, F; Bonci, E; Anania, C; Romaggioli, S; Chiesa, C. (2013). Upper limit of normal for alanine aminotransferase: Quo vadis? 422: 29–39. 10.1016/j.cca.2013.03.030.
Padula, AM; Ning, X; Bakre, S; Barrett, ES; Bastain, T; Bennett, DH; Bloom, MS; Breton, CV; Dunlop, AL; Eick, SM; Ferrara, A; Fleisch, A; Geiger, S; Goin, DE; Kannan, K; Karagas, MR; Korrick, S; Meeker, JD; Morello-Frosch, R. (2023). Birth outcomes in relation to prenatal exposure to per-and polyfluoroalkyl substances and stress in the environmental influences on child health outcomes (echo) program [Supplemental Data]. Environ Health Perspect 131: (037006) 037001–037011. 10.1289/EHP10723.36920051
Pan, Y; Qin, H; Liu, W; Zhang, Q; Zheng, L; Zhou, C; Quan, X. (2019). Effects of chlorinated polyfluoroalkyl ether sulfonate in comparison with perfluoroalkyl acids on gene profiles and stemness in human mesenchymal stem cells. Chemosphere 237: 124402. 10.1016/j.chemosphere.2019.124402.31352096
Pan, Y; Zhu, Y; Zheng, T; Cui, Q; Buka, SL; Zhang, B; Guo, Y; Xia, W; Yeung, LW; Li, Y; Zhou, A; Qiu, L; Liu, H; Jiang, M; Wu, C; Xu, S; Dai, J. (2017). Novel Chlorinated Polyfluorinated Ether Sulfonates and Legacy Per-/Polyfluoroalkyl Substances: Placental Transfer and Relationship with Serum Albumin and Glomerular Filtration Rate. Environ Sci Technol 51: 634–644. 10.1021/acs.est.6b04590.27931097
Pan, Z; Guo, Y; Zhou, Q; Wang, Q; Pan, S; Xu, S; Li, L. (2023). Perfluoroalkyl substance exposure is associated with asthma and innate immune cell count in US adolescents stratified by sex. Environ Sci Pollut Res Int 30: 52535–52548. 10.1007/s11356-023-26065-7.36840869
Papadopoulou, E; Sabaredzovic, A; Namork, E; Nygaard, UC; Granum, B; Haug, LS. (2016). Exposure of Norwegian toddlers to perfluoroalkyl substances (PFAS): The association with breastfeeding and maternal PFAS concentrations. Environ Int 94: 687–694. 10.1016/j.envint.2016.07.006.27453094
Park, JH; Choi, J; Jun, DW; Han, SW; Yeo, YH; Nguyen, MH. (2019). Low Alanine Aminotransferase Cut-Off for Predicting Liver Outcomes; A Nationwide Population-Based Longitudinal Cohort Study. J Clin Med 8. 10.3390/jcm8091445.
Park, SJ; Sim, KH; Shrestha, P; Yang, JH; Lee, YJ. (2021). Perfluorooctane sulfonate and bisphenol A induce a similar level of mast cell activation via a common signaling pathway, Fyn-Lyn-Syk activation. Food Chem Toxicol 156: 112478. 10.1016/j.fct.2021.112478.34363875
Park, SK; Wang, X; Ding, N; Karvonen-Gutierrez, CA; Calafat, AM; Herman, WH; Mukherjee, B; Harlow, SD. (2022). Per- and polyfluoroalkyl substances and incident diabetes in midlife women: the Study of Women’s Health Across the Nation (SWAN). Diabetologia 65: 1157–1168. 10.1007/s00125-022-05695-5.35399113
Passen, EL; Andersen, BR. (1986). Clinical tetanus despite a protective level of toxin-neutralizing antibody [Case Report]. JAMA 255: 1171–1173. 10.1001/jama.1986.03370090093029.2868135
Patel, JC; Mehta, BC. (1999). Tetanus: Study of 8,697 cases. Indian J Med Sci 53: 393–401.10710833
Patlewicz, G; Richard, A; Williams, A; Judson, R; Thomas, R. (2022). Towards reproducible structure-based chemical categories for PFAS to inform and evaluate toxicity and toxicokinetic testing. Computational Toxicology 24: 100250. 10.1016/j.comtox.2022.100250.
Peterson, AK; Eckel, SP; Habre, R; Yang, T; Faham, D; Amin, M; Grubbs, BH; Farzan, SF; Kannan, K; Robinson, M; Lerner, D; Al-Marayati, LA; Walker, DK; Grant, EG; Breton, CV; Bastain, TM. (2022). Detected prenatal perfluorooctanoic acid (PFOA) exposure is associated with decreased fetal head biometric parameters in participants experiencing higher perceived stress during pregnancy in the MADRES cohort. 9. 10.1016/j.envadv.2022.100286.
Petro, EM; D’Hollander, W; Covaci, A; Bervoets, L; Fransen, E; De Neubourg, D; De Pauw, I; Leroy, JL; Jorssen, EP; Bols, PE. (2014). Perfluoroalkyl acid contamination of follicular fluid and its consequence for in vitro oocyte developmental competence. Sci Total Environ 496: 282–288. 10.1016/j.scitotenv.2014.07.028.25089690
Petroff, RL; Cavalcante, RG; Langen, ES; Dolinoy, DC; Padmanabhan, V; Goodrich, JM. (2023). Mediation effects of DNA methylation and hydroxymethylation on birth outcomes after prenatal per- and polyfluoroalkyl substances (PFAS) exposure in the Michigan mother-infant Pairs cohort. Clinical Epigenetics 15: 49. 10.1186/s13148-023-01461-5.36964604
Pfohl, M; Ingram, L; Marques, E; Auclair, A; Barlock, B; Jamwal, R; Anderson, D; Cummings, BS; Slitt, AL. (2020). Perfluorooctanesulfonic acid and perfluorohexanesulfonic acid alter the blood lipidome and the hepatic proteome in a murine model of diet-induced obesity. Toxicol Sci 178: 311–324. 10.1093/toxsci/kfaa148.32991729
Phelps, DW; Palekar, AI; Conley, HE; Ferrero, G; Driggers, JH; Linder, KE; Kullman, SW; Reif, DM; Sheats, MK; Dewitt, JC; Yoder, JA. (2023). Legacy and emerging per- and polyfluoroalkyl substances suppress the neutrophil respiratory burst. J Immunotoxicol 20: 2176953. 10.1080/1547691X.2023.2176953.36788734
Pirard, C; Dufour, P; Charlier, C. (2020). Background contamination of perfluoralkyl substances in a Belgian general population. Toxicol Lett 333: 13–21. 10.1016/j.toxlet.2020.07.015.32659468
Porter, AK; Kleinschmidt, SE; Andres, KL; Reusch, CN; Krisko, RM; Taiwo, OA; Olsen, GW; Longnecker, MP. (2022). Antibody response to COVID-19 vaccines among workers with a wide range of exposure to per- and polyfluoroalkyl substances. Environ Int 169: 107537. 10.1016/j.envint.2022.107537.36183490
Preston, EV; Rifas-Shiman, SL; Hivert, MF; Zota, AR; Sagiv, SK; Calafat, AM; Oken, E; James-Todd, T. (2020). Associations of per- and polyfluoroalkyl substances (PFAS) with glucose tolerance during pregnancy in project viva. J Clin Endocrinol Metab 105: E2864–E2876. 10.1210/clinem/dgaa328.32480407
Purdue, MP; Rhee, J; Denic-Roberts, H; Mcglynn, KA; Byrne, C; Sampson, J; Botelho, JC; Calafat, AM; Rusiecki, J. (2023). A nested case-control study of serum per- and polyfluoroalkyl substances and testicular germ cell tumors among U.S. Air Force servicemen. Environ Health Perspect 131: 77007. 10.1289/EHP12603.37458713
Qin, W; Henneberger, L; Huchthausen, J; König, M; Escher, BI. (2023a). Role of bioavailability and protein binding of four anionic perfluoroalkyl substances in cell-based bioassays for quantitative in vitro to in vivo extrapolations. Environ Int 173: 107857. 10.1016/j.envint.2023.107857.36881956
Qin, WP; Cao, LY; Li, CH; Guo, LH; Colbourne, J; Ren, XM. (2020). Perfluoroalkyl Substances Stimulate Insulin Secretion by Islet β Cells via G Protein-Coupled Receptor 40. Environ Sci Technol 54: 3428–3436. 10.1021/acs.est.9b07295.32092270
Qin, XD; Zhou, Y; Bloom, MS; Qian, ZM; Geiger, SD; Vaughn, MG; Chu, C; Li, QQ; Yang, BY; Hu, LW; Yu, Y; Zeng, XW; Dong, GH. (2023b). Prenatal Exposure to PFAS, Associations with Preterm Birth and Modification by Maternal Estrogen Levels: The Maoming Birth Study. Environ Health Perspect 131: 117006. 10.1289/EHP11377.37962440
Qiu, Z; Qu, K; Luan, F; Liu, Y; Zhu, Y; Yuan, Y; Li, H; Zhang, H; Hai, Y; Zhao, C. (2020). Binding specificities of estrogen receptor with perfluorinated compounds: A cross species comparison. Environ Int 134: 105284. 10.1016/j.envint.2019.105284.31707300
Radke, E; Wright, MJ; Christensen, K; Lin, CJ; Goldstone, AE; Glenn, B; Thayer, K. (2022). Epidemiology evidence for health effects of 150 per- and polyfluoroalkyl substances: A systematic evidence map [Review]. Environ Health Perspect 130: 96003. 10.1289/EHP11185.36178797
Ramhøj, L; Hass, U; Boberg, J; Scholze, M; Christiansen, S; Nielsen, F; Axelstad, M. (2018). Perfluorohexane sulfonate (PFHxS) and a mixture of endocrine disrupters reduce thyroxine levels and cause anti-androgenic effects in rats. Toxicol Sci 163: 579–591. 10.1093/toxsci/kfy055.29518214
Ramhøj, L; Hass, U; Gilbert, ME; Wood, C; Svingen, T; Usai, D; Vinggaard, AM; Mandrup, K; Axelstad, M. (2020). Evaluating thyroid hormone disruption: investigations of long-term neurodevelopmental effects in rats after perinatal exposure to perfluorohexane sulfonate (PFHxS). Sci Rep 10: 2672. 10.1038/s41598-020-59354-z.32060323
Ramli, MR; Yoneda, M; Ali Mohd, M; Mohamad Haron, DE; Ahmad, ED. (2020). Level and determinants of serum perfluoroalkyl acids (PFAAs) in a population in Klang Valley, Malaysia. Int J Hyg Environ Health 223: 179–186. 10.1016/j.ijheh.2019.09.005.31542349
Rantakokko, P; Männistö, V; Airaksinen, R; Koponen, J; Viluksela, M; Kiviranta, H; Pihlajamäki, J. (2015). Persistent organic pollutants and non-alcoholic fatty liver disease in morbidly obese patients: A cohort study. Environ Health 14: 79. 10.1186/s12940-015-0066-z.26420011
Refetoff, S. (2015). Thyroid hormone serum transport proteins. In KR Feingold; B Anawalt; A Boyce; G Chrousos; WW de Herder; K Dhatariya; K Dungan; JM Hershman; J Hofland; S Kalra; G Kaltsas; C Koch; P Kopp; M Korbonits; CS Kovacs; W Kuohung; B Laferrère; M Levy; EA McGee; R McLachlan; JE Morley; M New; J Purnell; R Sahay; F Singer; MA Sperling; CA Stratakis; DL Trence; DP Wilson (Eds.), Endotext. South Dartmouth, MA: MDtext.com Inc. https://www.ncbi.nlm.nih.gov/books/NBK285566/.
Ren, XM; Qin, WP; Cao, LY; Zhang, J; Yang, Y; Wan, B; Guo, LH. (2016). Binding interactions of perfluoroalkyl substances with thyroid hormone transport proteins and potential toxicological implications. Toxicology 366–367: 32–42. 10.1016/j.tox.2016.08.011.
Ren, XM; Zhang, YF; Guo, LH; Qin, ZF; Lv, QY; Zhang, LY. (2015). Structure-activity relations in binding of perfluoroalkyl compounds to human thyroid hormone T3 receptor. Arch Toxicol 89: 233–242. 10.1007/s00204-014-1258-y.24819616
Rericha, Y; Cao, D; Truong, L; Simonich, M; Field, JA; Tanguay, RL. (2021). Behavior effects of structurally diverse per- and polyfluoroalkyl substances in zebrafish. Chem Res Toxicol 34: 1409–1416. 10.1021/acs.chemrestox.1c00101.34018735
Reyes, L; Mañalich, R. (2005). Long-term consequences of low birth weight [Review]. Kidney Int Suppl 68: S107–S111. 10.1111/j.1523-1755.2005.09718.x.
Rhee, J; Barry, KH; Huang, WY; Sampson, JN; Hofmann, JN; Silverman, DT; Calafat, AM; Botelho, JC; Kato, K; Purdue, MP; Berndt, SI. (2023). A prospective nested case-control study of serum concentrations of per- and polyfluoroalkyl substances and aggressive prostate cancer risk. Environ Res 228: 115718. 10.1016/j.envres.2023.115718.36958379
Rivera-Núñez, Z; Kinkade, CW; Khoury, L; Brunner, J; Murphy, H; Wang, C; Kannan, K; Miller, RK; O’Connor, TG; Barrett, ES. (2023). Prenatal perfluoroalkyl substances exposure and maternal sex steroid hormones across pregnancy. Environ Res 220: 115233. 10.1016/j.envres.2023.115233.36621543
Rosen, EM; Kotlarz, N; Knappe, DRU; Lea, CS; Collier, DN; Richardson, DB; Hoppin, JA. (2022). Drinking water-associated PFAS and fluoroethers and lipid outcomes in the GenX exposure study. Environ Health Perspect 130: 97002. 10.1289/EHP11033.36069575
Roth, K; Yang, Z; Agarwal, M; Birbeck, J; Westrick, J; Lydic, T; Gurdziel, K; Petriello, MC. (2024). Exposure of Environ Health Perspect 132: 087007. 10.1289/EHP14339.39177951
Ru, H. (2024). Dose-response modeling files for the epidemiological birth weight and ALT of the PFHxS IRIS Assessment.
Ru, H; Lee, AL; Rappazzo, KM; Dzierlenga, M; Radke, E; Bateson, TF; Wright, JM. (2024). Systematic review and meta-analysis of birth weight and perfluorohexane sulfonate exposures: examination of sample timing and study confidence. Occup Environ Med 81: 266–276. 10.1136/oemed-2023-109328.38724253
Rylander, C; Phi, DT; Odland, JØ; Sandanger, TM. (2009). Perfluorinated compounds in delivering women from south central Vietnam. J Environ Monit 11: 2002–2008. 10.1039/b908551c.19890557
Sagiv, SK; Rifas-Shiman, SL; Fleisch, AF; Webster, TF; Calafat, AM; Ye, X; Gillman, MW; Oken, E. (2018). Early Pregnancy Perfluoroalkyl Substance Plasma Concentrations and Birth Outcomes in Project Viva: Confounded by Pregnancy Hemodynamics? Am J Epidemiol 187: 793–802. 10.1093/aje/kwx332.29155920
Salihović, S; Dickens, AM; Schoultz, I; Fart, F; Sinisalu, L; Lindeman, T; Halfvarson, J; Orešič, M; Hyötyläinen, T. (2019). Simultaneous determination of perfluoroalkyl substances and bile acids in human serum using ultra-high-performance liquid chromatography-tandem mass spectrometry. Anal Bioanal Chem 412: 2251–2259. 10.1007/s00216-019-02263-6.31760452
Salvatier, J; Wiecki, TV; Fonnesbeck, C. (2016). Probabilistic programming in Python using PyMC3. PeerJ Computer Science 2: e55. 10.7717/peerj-cs.55.
Sanghavi, M; Rutherford, JD. (2014). Cardiovascular physiology of pregnancy. Circulation 130: 1003–1008. 10.1161/CIRCULATIONAHA.114.009029.25223771
Schillemans, T; Iszatt, N; Remy, S; Schoeters, G; Fernández, MF; D’Cruz, SC; Desalegn, A; Haug, LS; Lignell, S; Lindroos, AK; Fábelová, L; Murinova, LP; Kosjek, T; Tkalec, Ž; Gabriel, C; Sarigiannis, D; Pedraza-Díaz, S; Esteban-López, M; Castaño, A; … Åkesson, A. (2022). Cross-sectional associations between exposure to per- and polyfluoroalkyl substances and body mass index among European teenagers in the HBM4EU aligned studies. Environ Pollut 316: 120566. 10.1016/j.envpol.2022.120566.36334774
Schlosser, P. (2024). Model code for classical pharmacokinetic modeling and alternate dosimetric analyses of PFDA and PFHxS in support of the IRIS toxicological reviews [Computer Program].
Schumann, G; Bonora, R; Ceriotti, F; Férard, G; Ferrero, CA; Franck, PFH; Gella, FJ; Hoelzel, W; Jørgensen, PJ; Kanno, T; Kessner, A; Klauke, R; Kristiansen, N; Lessinger, JM; Linsinger, TPJ; Misaki, H; Panteghini, M; Pauwels, J; Schiele, F; Schimmel, HG. (2002). IFCC primary reference procedures for the measurement of catalytic activity concentrations of enzymes at 37°C. Part 4. Reference procedure for the measurement of catalytic concentration of alanine aminotransferase. Clin Chem Lab Med 40: 718–724. 10.1515/CCLM.2002.124.12241021
Schumann, G; Klauke, R. (2003). New IFCC reference procedures for the determination of catalytic activity concentrations of five enzymes in serum: preliminary upper reference limits obtained in hospitalized subjects. 327: 69–79. 10.1016/s0009-8981(02)00341-8.
Selgrade, MK. (2007). Immunotoxicity: The risk is real [Review]. Toxicol Sci 100: 328–332. 10.1093/toxsci/kfm244.17878151
Shearer, JJ; Callahan, CL; Calafat, AM; Huang, WY; Jones, RR; Sabbisetti, VS; Freedman, ND; Sampson, JN; Silverman, DT; Purdue, MP; Hofmann, JN. (2021). Serum concentrations of per- and polyfluoroalkyl substances and risk of renal cell carcinoma. J Natl Cancer Inst 113: 580–587. 10.1093/jnci/djaa143.32944748
Shen, Z; Ge, J; Ye, H; Tang, S; Li, Y. (2020). Cholesterol-like Condensing Effect of Perfluoroalkyl Substances on a Phospholipid Bilayer. J Phys Chem B 124: 5415–5425. 10.1021/acs.jpcb.0c00980.32515593
Shi, S; Ding, Y; Wu, B; Hu, P; Chen, M; Dong, N; Vinturache, A; Gu, H; Dong, X; Ding, G. (2023). Association of perfluoroalkyl substances with pulmonary function in adolescents (NHANES 2007-2012). Environ Sci Pollut Res Int. 10.1007/s11356-023-26119-w.
Shi, Y; Yang, L; Li, J; Lai, J; Wang, Y; Zhao, Y; Wu, Y. (2017). Occurrence of perfluoroalkyl substances in cord serum and association with growth indicators in newborns from Beijing. Chemosphere 169: 396–402. 10.1016/j.chemosphere.2016.11.050.27886542
Shirke, AV; Radke, EG; Jones, R; Allen, B; Blain, R; Lin, C; Vetter, N; Lemeris, C; Hartman, P; Hubbard, H; Williams, AJ; Thayer, KA; Carlson, LM. (2024). Systematic evidence map for the per- and polyfluoroalkyl substances (PFAS) universe.
Shiue, I. (2015a). Arsenic, heavy metals, phthalates, pesticides, hydrocarbons and polyfluorinated compounds but not parabens or phenols are associated with adult remembering condition: US NHANES, 2011-2012. Environ Sci Pollut Res Int 22: 6381–6386. 10.1007/s11356-015-4261-9.25744817
Shiue, I. (2015b). Urinary heavy metals, phthalates and polyaromatic hydrocarbons independent of health events are associated with adult depression: USA NHANES, 2011-2012. Environ Sci Pollut Res Int 22: 17095–17103. 10.1007/s11356-015-4944-2.26126689
Shiue, I. (2015c). Urinary heavy metals, phthalates, perchlorate, nitrate, thiocyanate, hydrocarbons, and polyfluorinated compounds are associated with adult hearing disturbance: USA NHANES, 2011-2012. Environ Sci Pollut Res Int 22: 20306–20311. 10.1007/s11356-015-5546-8.26490897
Shiue, I. (2015d). Urinary heavy metals, phthalates, phenols, thiocyanate, parabens, pesticides, polyaromatic hydrocarbons but not arsenic or polyfluorinated compounds are associated with adult oral health: USA NHANES, 2011-2012. Environ Sci Pollut Res Int 22: 15636–15645. 10.1007/s11356-015-4749-3.26018285
Shoaff, J; Papandonatos, GD; Calafat, AM; Chen, A; Lanphear, BP; Ehrlich, S; Kelsey, KT; Braun, JM. (2018). Prenatal exposure to perfluoroalkyl substances: Infant birth weight and early life growth. Environmental Epidemiology 2: e010. 10.1097/EE9.0000000000000010.30272047
Shoaff, JR. (2018). [Email to Michael Wright in response to a question about Shoaff et al. 2018].
Sim, KH; Oh, HS; Lee, C; Eun, H; Lee, YJ. (2023). Evaluation of the Effect of Perfluorohexane Sulfonate on the Proliferation of Human Liver Cells. Int J Environ Res Public Health 20. 10.3390/ijerph20196868.
Siwakoti, RC; Cathey, A; Ferguson, KK; Hao, W; Cantonwine, DE; Mukherjee, B; Mcelrath, TF; Meeker, JD. (2023). Prenatal per- and polyfluoroalkyl substances (PFAS) exposure in relation to preterm birth subtypes and size-for-gestational age in the LIFECODES cohort 2006-2008. Environ Res 237: 116967. 10.1016/j.envres.2023.116967.37634691
Søderstrøm, S; Lille-Langøy, R; Yadetie, F; Rauch, M; Milinski, A; Dejaegere, A; Stote, RH; Goksøyr, A; Karlsen, OA. (2022). Agonistic and potentiating effects of perfluoroalkyl substances (PFAS) on the Atlantic cod (Gadus morhua) peroxisome proliferator-activated receptors (Ppars). Environ Int 163: 107203. 10.1016/j.envint.2022.107203.35364415
Solan, ME; Koperski, CP; Senthilkumar, S; Lavado, R. (2023). Short-chain per- and polyfluoralkyl substances (PFAS) effects on oxidative stress biomarkers in human liver, kidney, muscle, and microglia cell lines. Environ Res 223: 115424–115424. 10.1016/j.envres.2023.115424.36740157
Sood, S; Ojo, AO; Adu, D; Kannan, K; Ghassabian, A; Koshy, T; Vento, SM; Pehrson, LJ; Gilbert, JF; Arogundade, FA; Ademola, AD; Salako, BO; Raji, Y; Osafo, C; Antwi, S; Trachtman, H; Trasande, L; Ajayi, S; Burke, D; Cooper, R; Gbadegesin, R; Ilori, T; Mamven, M; Olanrewaju, T; Parekh, R; Rhule, J; Salako, T; Tayo, B; Ulasi, I; Investigators, HAKDRN. (2019). Association Between Perfluoroalkyl Substance Exposure and Renal Function in Children With CKD Enrolled in H3Africa Kidney Disease Research Network. 4: 1641–1645. 10.1016/j.ekir.2019.07.017.
Sørli, JB; Låg, M; Ekeren, L; Perez-Gil, J; Haug, LS; Da Silva, E; Matrod, MN; Gützkow, KB; Lindeman, B. (2020). Per- and polyfluoroalkyl substances (PFASs) modify lung surfactant function and pro-inflammatory responses in human bronchial epithelial cells. Toxicol In Vitro 62: 104656. 10.1016/j.tiv.2019.104656.31536757
Starling, AP; Adgate, JL; Hamman, RF; Kechris, K; Calafat, AM; Ye, X; Dabelea, D. (2017). Perfluoroalkyl substances during pregnancy and offspring weight and adiposity at birth: Examining mediation by maternal fasting glucose in the healthy start study. Environ Health Perspect 125: 067016. 10.1289/EHP641.28669937
Steenland, K; Barry, V; Savitz, D. (2018a). Serum perfluorooctanoic acid and birthweight: an updated meta-analysis with bias analysis. Epidemiology 29: 765–776. 10.1097/EDE.0000000000000903.30063543
Steenland, K; Kugathasan, S; Barr, DB. (2018b). PFOA and ulcerative colitis. Environ Res 165: 317–321. 10.1016/j.envres.2018.05.007.29777922
Stoker, TE; Wang, J; Murr, AS; Bailey, J. R.; Buckalew, AR. (2023). High-Throughput Screening of ToxCast PFAS Chemical Library for Potential Inhibitors of the Human Sodium Iodide Symporter. Chem Res Toxicol 36: 380–389. 10.1021/acs.chemrestox.2c00339.36821091
Sundström, M; Chang, SC; Noker, PE; Gorman, GS; Hart, JA; Ehresman, DJ; Bergman, A; Butenhoff, JL. (2012). Comparative pharmacokinetics of perfluorohexanesulfonate (PFHxS) in rats, mice, and monkeys. Reprod Toxicol 33: 441–451. 10.1016/j.reprotox.2011.07.004.21856411
Taibl, KR; Liang, D; Dunlop, AL; Barr, DB; Smith, MR; Steenland, K; Tan, Y; Ryan, PB; Panuwet, P; Everson, T; Marsit, CJ; Kannan, K; Jones, DP; Eick, SM. (2023). Pregnancy-related hemodynamic biomarkers in relation to trimester-specific maternal per - and polyfluoroalkyl substances exposures and adverse birth outcomes. Environ Pollut 323: 121331. 10.1016/j.envpol.2023.121331.36813097
Takacs, ML; Abbott, BD. (2007). Activation of mouse and human peroxisome proliferator-activated receptors (alpha, beta/delta, gamma) by perfluorooctanoic acid and perfluorooctane sulfonate. Toxicol Sci 95: 108–117. 10.1093/toxsci/kfl135.17047030
Tan, Y; Zeng, Z; Liang, H; Weng, X; Yao, H; Fu, Y; Li, Y; Chen, J; Wei, X; Jing, C. (2022). Association between Perfluoroalkyl and Polyfluoroalkyl Substances and Women’s Infertility, NHANES 2013-2016. Int J Environ Res Public Health 19. 10.3390/ijerph192215348.
Taylor, KW; Hoffman, K; Thayer, KA; Daniels, JL. (2014). Polyfluoroalkyl chemicals and menopause among women 20-65 years of age (NHANES). Environ Health Perspect 122: 145–150. 10.1289/ehp.1306707.24280566
Tetzlaff, CNR; Ramhøj, L; Lardenois, A; Axelstad, M; Evrard, B; Chalmel, F; Taxvig, C; Svingen, T. (2021). Adult female rats perinatally exposed to perfluorohexane sulfonate (PFHxS) and a mixture of endocrine disruptors display increased body/fat weights without a transcriptional footprint in fat cells. Toxicol Lett 339: 78–87. 10.1016/j.toxlet.2020.12.018.33387635
Thulin, P; Nordahl, G; Gry, M; Yimer, G; Aklillu, E; Makonnen, E; Aderaye, G; Lindquist, L; Mattsson, CM; Ekblom, B; Antoine, DJ; Park, BK; Linder, S; Harrill, AH; Watkins, PB; Glinghammar, B; Schuppe-Koistinen, I. (2014). Keratin-18 and microRNA-122 complement alanine aminotransferase as novel safety biomarkers for drug-induced liver injury in two human cohorts. Liver Int 34: 367–378. 10.1111/liv.12322.24118944
Tian, M, .; Reichetzeder, C, .; Li, J, .; Hocher, B, . (2019a). Low birth weight, a risk factor for diseases in later life, is a surrogate of insulin resistance at birth. J Hypertens 37: 2123–2134. 10.1097/HJH.0000000000002156.31157747
Tian, YP; Zeng, XW; Bloom, MS; Lin, S; Wang, SQ; Yim, SHL; Yang, M; Chu, C; Gurram, N; Hu, LW; Liu, KK; Yang, BY; Feng, D; Liu, RQ; Nian, M; Dong, GH. (2019b). Isomers of perfluoroalkyl substances and overweight status among Chinese by sex status: Isomers of C8 Health Project in China. Environ Int 124: 130–138. 10.1016/j.envint.2019.01.006.30641256
Tillaut, H; Monfort, C; Giton, F; Warembourg, C; Rouget, F; Cordier, S; Laine, F; Gaudreau, E; Garlantezec, R; Saint-Amour, D; Chevrier, C. (2022). Persistent organic pollutant exposure and thyroid function among 12-year-old children. Neuroendocrinology. 10.1159/000528631.
Tsai, MS; Miyashita, C; Araki, A; Itoh, S; Bamai, YA; Goudarzi, H; Okada, E; Kashino, I; Matsuura, H; Kishi, R. (2018). Determinants and temporal trends of perfluoroalkyl substances in pregnant women: The Hokkaido study on environment and children’s health. Int J Environ Res Public Health 15: 989. 10.3390/ijerph15050989.29758015
U.S. EPA (U.S. Environmental Protection Agency). (2002). A review of the reference dose and reference concentration processes [EPA Report]. (EPA630P02002F). Washington, DC. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2005). Guidelines for carcinogen risk assessment [EPA Report]. (EPA630P03001F). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/cancer guidelines final3-25-05.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2012). Benchmark dose technical guidance [EPA Report]. (EPA100R12001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/benchmark-dose-technical-guidance.
U.S. EPA (U.S. Environmental Protection Agency). (2015). Peer review handbook [EPA Report] (4th ed.). (EPA/100/B-15/001). Washington, DC: U.S. Environmental Protection Agency, Science Policy Council. https://www.epa.gov/osa/peer-review-handbook-4th-edition-2015.
U.S. EPA (U.S. Environmental Protection Agency). (2016a). Health effects support document for perfluorooctane sulfonate (PFOS) [EPA Report]. (EPA 822-R-16-002). Washington, DC: U.S. Environmental Protection Agency, Office of Water, Health and Ecological Criteria Division. https://www.epa.gov/sites/production/files/2016-05/documents/pfoshesdfinal508.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2016b). Health effects support document for perfluorooctanoic acid (PFOA) [EPA Report]. (EPA 822-R-16-003). Washington, DC: U.S. Environmental Protection Agency, Office of Water, Health and Ecological Criteria Division. https://www.epa.gov/sites/production/files/2016-05/documents/pfoahesdfinal-plain.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2019a). CompTox Chemicals Dashboard [Database]. Research Triangle Park, NC. Retrieved from https://comptox.epa.gov/dashboard
U.S. EPA (U.S. Environmental Protection Agency). (2019b). Systematic review protocol for the PFBA, PFHxA, PFHxS, PFNA, and PFDA IRIS assessments [EPA Report]. (EPA635R19050). Integrated Risk Information System. Center for Public Health and Environmental Assessment. Office of Research and Development. U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/irisdrafts/recordisplay.cfm?deid=345065.
U.S. EPA (U.S. Environmental Protection Agency). (2020). ORD staff handbook for developing IRIS assessments (public comment draft) [EPA Report]. (EPA600R20137). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Center for Public Health and Environmental Assessment. https://cfpub.epa.gov/ncea/irisdrafts/recordisplay.cfm?deid=350086.
U.S. EPA (U.S. Environmental Protection Agency). (2021a). Human health toxicity values for perfluorobutane sulfonic acid (CASRN 375-73-5) and related compound potassium perfluorobutane sulfonate (CASRN 29420-49-3) [EPA Report]. (EPA/600/R-20/345F). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=350888.
U.S. EPA (U.S. Environmental Protection Agency). (2021b). Toxicological review of perfluorobutanoic acid (PFBA) and related compound ammonium perfluorobutanoic acid (public comment and external review draft, Aug 2021) [EPA Report]. (EPA/635/R-20/424a). Washington, DC: U.S. Environmental Protection Agency, Integrated Risk Information System. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P1014IBF.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2022a). DRAFT: Toxicological review of perfluorohexanoic acid [CASRN 307244] and related salts. (EPA/635/R-21/312a).
U.S. EPA (U.S. Environmental Protection Agency). (2022b). ORD staff handbook for developing IRIS assessments. (EPA 600/R-22/268). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Center for Public Health and Environmental Assessment. https://cfpub.epa.gov/ncea/irisdrafts/recordisplay.cfm?deid=356370.
U.S. EPA (U.S. Environmental Protection Agency). (2022c). Review of EPA’s analyses to support EPA’s national primary drinking water rulemaking for PFAS. (EPA-SAB-22-008). https://sab.epa.gov/ords/sab/f?p=100:18:16490947993:::18:P18ID:2601.
U.S. EPA (U.S. Environmental Protection Agency). (2023a). IRIS toxicological review of perfluorodecanoic acid (PFDA) and related salts (public comment and external review draft). (EPA/635/R-23/056a). https://cfpub.epa.gov/ncea/irisdrafts/recordisplay.cfm?deid=354408.
U.S. EPA (U.S. Environmental Protection Agency). (2023b). Toxicological Review of Perfluorohexanoic Acid (PFHxA) and Related Salts (Final Report, 2023) [EPA Report]. (EPA/635/R-23/027F). https://cfpub.epa.gov/ncea/irisdrafts/recordisplay.cfm?deid=357314.
Valenti, L, . ; Pelusi, S, .; Bianco, C, .; Ceriotti, F, . ; Berzuini, A, . ; Iogna Prat, L, . ; Trotti, R, . ; Malvestiti, F, . ; D’Ambrosio, R, . ; Lampertico, P, .; Colli, A, . ; Colombo, M, . ; Tsochatzis, E, . A. ; Fraquelli, M, . ; Prati, D, . (2021). Definition of Healthy Ranges for Alanine Aminotransferase Levels: A 2021 Update. Hematology 5: 1824–1832. 10.1002/hep4.1794.
Valvi, D; Oulhote, Y; Weihe, P; Dalgård, C; Bjerve, KS; Steuerwald, U; Grandjean, P. (2017). Gestational diabetes and offspring birth size at elevated environmental pollutant exposures. Environ Int 107: 205–215. 10.1016/j.envint.2017.07.016.28753482
Van Larebeke, N; Koppen, G; De Craemer, S; Colles, A; Bruckers, L; Den Hond, E; Govarts, E; Morrens, B; Schettgen, T; Remy, S; Coertjens, D; Nawrot, T; Nelen, V; Baeyens, W; Schoeters, G. (2023). Per- and polyfluoroalkyl substances (PFAS) and immune system-related diseases: Results from the Flemish Environment and Health Study (FLEHS) 2008–2014. Environ Sci Eur 35: 28. 10.1186/s12302-023-00731-6.
van Larebeke, N; Koppen, G; Decraemer, S; Colles, A; Bruckers, L; Den Hond, E; Govarts, E; Morrens, B; Schettgen, T; Remy, S; Coertjens, D; Nawrot, T, im; Nelen, V; Baeyens, W; Schoeters, G. (2022). Per- and polyfluoroalkyl substances (PFAS) and neurobehavioral function and cognition in adolescents (2010-2011) and elderly people (2014): Results from the Flanders Environment and Health Studies (FLEHS). Environ Sci Eur 34: 98. 10.1186/s12302-022-00675-3.
Viberg, H; Lee, I; Eriksson, P. (2013). Adult dose-dependent behavioral and cognitive disturbances after a single neonatal PFHxS dose. Toxicology 304: 185–191. 10.1016/j.tox.2012.12.013.23287389
Viechtbauer, W. (2010). Conducting meta-analyses in R with the metafor package. J Stat Softw 36: 1–48.
Vilhelmsson, A; Rylander, L; Jöud, A; Lindh, CH; Mattsson, K; Liew, Z; Guo, P; Ritz, B; Källén, K; Thacher, JD. (2023). Exposure to per- and polyfluoroalkyl substances in early pregnancy and risk of cerebral palsy in children. Sci Total Environ 899: 165622. 10.1016/j.scitotenv.2023.165622.37474063
Vogs, C; Johanson, G; Näslund, M; Wulff, S; Sjödin, M; Hellstrandh, M; Lindberg, J; Wincent, E. (2019). Toxicokinetics of perfluorinated alkyl acids influences their toxic potency in the Zebrafish embryo (Danio rerio). Environ Sci Technol 53: 3898–3907. 10.1021/acs.est.8b07188.30844262
Vongphachan, V; Cassone, CG; Wu, DM; Chiu, SZ; Crump, D; Kennedy, SW. (2011). Effects of perfluoroalkyl compounds on mRNA expression levels of thyroid hormone-responsive genes in primary cultures of avian neuronal cells. Toxicol Sci 120: 392–402. 10.1093/toxsci/kfq395.21212296
Wahlang, B; Beier, JI; Clair, HB; Bellis-Jones, HJ; Falkner, K; Mcclain, CJ; Cave, MC. (2013). Toxicant-associated steatohepatitis [Review]. Toxicol Pathol 41: 343–360. 10.1177/0192623312468517.23262638
Wallace, KB; Kissling, GE; Melnick, RL; Blystone, CR. (2013). Structure-activity relationships for perfluoroalkane-induced in vitro interference with rat liver mitochondrial respiration. Toxicol Lett 222: 257–264. 10.1016/j.toxlet.2013.07.025.23954199
Wang, B; Chen, Q; Shen, L; Zhao, S; Pang, W; Zhang, J. (2016). Perfluoroalkyl and polyfluoroalkyl substances in cord blood of newborns in Shanghai, China: Implications for risk assessment [Review]. Environ Int 97: 7–14. 10.1016/j.envint.2016.10.008.27770709
Wang, B; Fu, J; Gao, K; Liu, Q; Zhuang, L; Zhang, G; Long, M; Na, J; Ren, M; Wang, A; Liang, R; Shen, G; Li, Z; Lu, Q. (2021). Early pregnancy loss: Do Per- and polyfluoroalkyl substances matter? Environ Int 157: 106837. 10.1016/j.envint.2021.106837.34454360
Wang, H; Li, W; Yang, J; Wang, Y; Du, H; Han, M; Xu, L; Liu, S; Yi, J; Chen, Y; Jiang, Q; He, G. (2023a). Gestational exposure to perfluoroalkyl substances is associated with placental DNA methylation and birth size. Sci Total Environ 858: 159747. 10.1016/j.scitotenv.2022.159747.36309289
Wang, H; Zhang, X; Liu, Y; Liu, J. (2018). Stabilization of Liposomes by Perfluorinated Compounds. ACS Omega 3: 15353–15360. 10.1021/acsomega.8b02448.30556004
Wang, W; Zhou, W; Wu, S; Liang, F; Li, Y; Zhang, J; Cui, L; Feng, Y; Wang, Y. (2019). Perfluoroalkyl substances exposure and risk of polycystic ovarian syndrome related infertility in Chinese women. Environ Pollut 247: 824–831. 10.1016/j.envpol.2019.01.039.30731307
Wang, Y; Wen, Z; Dong, J. (2020). The city-level precision industrial emission reduction management based on enterprise performance evaluation and path design: A case of Changzhi, China. Sci Total Environ 734: 139350. 10.1016/j.scitotenv.2020.139350.32460075
Wang, Z; Zhang, J; Dai, Y; Zhang, L; Guo, J; Xu, S; Chang, X; Wu, C; Zhou, Z. (2023b). Mediating effect of endocrine hormones on association between per- and polyfluoroalkyl substances exposure and birth size: Findings from sheyang mini birth cohort study. Environ Res 226: 115658. 10.1016/j.envres.2023.115658.36894112
Weatherly, LM; Shane, HL; Jackson, LG; Lukomska, E; Baur, R; Cooper, MP; Anderson, SE. (2024). Systemic and immunotoxicity induced by topical application of perfluorohexane sulfonic acid (PFHxS) in a murine model. Food Chem Toxicol 186: 114578. 10.1016/j.fct.2024.114578.38458531
Weiss, JM; Andersson, PL; Lamoree, MH; Leonards, PEG; van Leeuwen, SPJ; Hamers, T. (2009). Competitive Binding of Poly- and Perfluorinated Compounds to the Thyroid Hormone Transport Protein Transthyretin. Toxicol Sci 109: 206–216. 10.1093/toxsci/kfp055.19293372
Weisskopf, MG; Seals, RM; Webster, TF. (2018). Bias amplification in epidemiologic analysis of exposure to mixtures. Environ Health Perspect 126. 10.1289/EHP2450.
Weisskopf, MG; Webster, TF. (2017). Trade-offs of personal versus more proxy exposure measures in environmental epidemiology. Epidemiology 28: 635–643. 10.1097/EDE.0000000000000686.28520644
Wen, HJ; Wang, SL; Chen, PC; Guo, YL. (2019). Prenatal perfluorooctanoic acid exposure and glutathione s-transferase T1/M1 genotypes and their association with atopic dermatitis at 2 years of age. PLoS ONE 14: e0210708. 10.1371/journal.pone.0210708.30650146
Whitworth, KW; Haug, LS; Baird, DD; Becher, G; Hoppin, JA; Eggesbo, M; Skjaerven, R; Thomsen, C; Longnecker, MP. (2012). P60—Preliminary results on subfecundity and plasma concentrations of perfluorinated compounds during pregnancy in the Norwegian Mother and Child Cohort Study, 2002–2004. Reprod Toxicol 33: 620–621. 10.1016/j.reprotox.2011.11.094.
Whitworth, KW; Haug, LS; Sabaredzovic, A; Eggesbo, M; Longnecker, MP. (2016). Brief Report: Plasma Concentrations of Perfluorooctane Sulfonamide and Time-to-pregnancy Among Primiparous Women. Epidemiology 27: 712–715. 10.1097/EDE.0000000000000524.27276029
Wielsøe, M; Eiberg, H; Ghisari, M; Kern, P; Lind, O; Bonefeld-Jørgensen, EC. (2018). Genetic variations, exposure to persistent organic pollutants and breast cancer risk - a greenlandic case-control study. Basic & Clinical Pharmacology & Toxicology Online Pharmacology Online 123: 335–346. 10.1111/bcpt.13002.
Wielsøe, M; Kern, P; Bonefeld-Jørgensen, EC. (2017). Serum levels of environmental pollutants is a risk factor for breast cancer in Inuit: a case control study. Environ Health 16: 56. 10.1186/s12940-017-0269-6.28610584
Wikström, S; Lin, PI; Lindh, CH; Shu, H; Bornehag, CG. (2020). Maternal serum levels of perfluoroalkyl substances in early pregnancy and offspring birth weight. Pediatr Res 87: 1093–1099. 10.1038/s41390-019-0720-1.31835271
Winquist, A; Hodge, JM; Diver, WR; Rodriguez, JL; Troeschel, AN; Daniel, J; Teras, LR. (2023). Case-Cohort Study of the Association between PFAS and Selected Cancers among Participants in the American Cancer Society’s Cancer Prevention Study II LifeLink Cohort. Environ Health Perspect 131: 127007. 10.1289/EHP13174.38088576
Woods, MM; Lanphear, BP; Braun, JM; McCandless, LC. (2017). Gestational exposure to endocrine disrupting chemicals in relation to infant birth weight: A Bayesian analysis of the HOME Study. Environ Health 16: 115. 10.1186/s12940-017-0332-3.29078782
Workman, CE; Becker, AB; Azad, MB; Moraes, TJ; Mandhane, PJ; Turvey, SE; Subbarao, P; Brook, JR; Sears, MR; Wong, CS. (2019). Associations between concentrations of perfluoroalkyl substances in human plasma and maternal, infant, and home characteristics in Winnipeg, Canada. Environ Pollut 249: 758–766. 10.1016/j.envpol.2019.03.054.30933773
Wright, JM; Larsen, A; Rappazzo, K; Ru, H; Radke, EG; Bateson, TF. (2023). Systematic review and meta-analysis of birthweight and PFNA exposures [Review]. Environ Res 222: 115357. 10.1016/j.envres.2023.115357.36706898
Xie, LN; Wang, XC; Su, LQ; Ji, SS; Gu, W; Barrett, H; Dong, XJ; Zhu, HJ; Hou, SS; Li, ZH; Liu, YL; Zhang, L; Zhu, Y. (2024). The association between per-/polyfluoroalkyl substances in serum and thyroid function parameters: A cross-sectional study on teenagers living near a Chinese fluorochemical industrial plant. Sci Total Environ 920: 170985. 10.1016/j.scitotenv.2024.170985.38367719
Xie, Y; Berntsen, HF; Zimmer, KE; Ropstad, E; Verhaegen, S; Connolly, L. (2021). Lipogenic Potency of Individual Perfluorinated Alkyl Acids (PFAAs) and Persistent Organic Pollutant (POP) Mixtures at Human Blood-Based Exposure Levels on Adipogenesis in 3T3-L1 Cells. Exposure and Health 14: 87–98. 10.1007/s12403-021-00420-w.
Xie, Z; Tan, J; Fang, G; Ji, H; Miao, M; Tian, Y; Hu, H; Cao, W; Liang, H; Yuan, W. (2022). Associations between prenatal exposure to perfluoroalkyl substances and neurobehavioral development in early childhood: A prospective cohort study. Ecotoxicol Environ Saf 241: 113818. 10.1016/j.ecoenv.2022.113818.35777342
Xiong, X; Chen, B; Wang, Z; Ma, L; Li, S; Gao, Y. (2022). Association between perfluoroalkyl substances concentration and bone mineral density in the US adolescents aged 12-19 years in NHANES 2005-2010. Front Endocrinol (Lausanne) 13: 980608. 10.3389/fendo.2022.980608.36277702
Xu, C; Yin, S; Liu, Y; Chen, F; Zhong, Z; Li, F; Liu, K; Liu, W. (2019). Prenatal exposure to chlorinated polyfluoroalkyl ether sulfonic acids and perfluoroalkyl acids: Potential role of maternal determinants and associations with birth outcomes. J Hazard Mater 380: 120867. 10.1016/j.jhazmat.2019.120867.31330388
Xu, C; Zhang, L; Zhou, Q; Ding, J; Yin, S; Shang, X; Tian, Y. (2022). Exposure to per- and polyfluoroalkyl substances as a risk factor for gestational diabetes mellitus through interference with glucose homeostasis. Sci Total Environ 838: 156561. 10.1016/j.scitotenv.2022.156561.35691348
Xu, H; Zhou, Q; Zhang, J; Chen, X; Zhao, H; Lu, H; Ma, B; Wang, Z; Wu, C; Ying, C; Xiong, Y; Zhou, Z; Li, X. (2020a). Exposure to elevated per- and polyfluoroalkyl substances in early pregnancy is related to increased risk of gestational diabetes mellitus: A nested case-control study in Shanghai, China. Environ Int 143: 105952. 10.1016/j.envint.2020.105952.32717645
Xu, M; Legradi, J; Leonards, P. (2021). Using comprehensive lipid profiling to study effects of PFHxS during different stages of early zebrafish development. Sci Total Environ 808: 151739. 10.1016/j.scitotenv.2021.151739.34848268
Xu, Y; Hansson, E; Andersson, EM; Jakobsson, K; Li, H. (2023a). High exposure to perfluoroalkyl substances in drinking water is associated with increased risk of osteoporotic fractures - A cohort study from Ronneby, Sweden. Environ Res 217: 114796. 10.1016/j.envres.2022.114796.36375499
Xu, Y; Jurkovic-Mlakar, S; Li, Y; Wahlberg, K; Scott, K; Pineda, D; Lindh, CH; Jakobsson, K; Engström, K. (2020b). Association between serum concentrations of perfluoroalkyl substances (PFAS) and expression of serum microRNAs in a cohort highly exposed to PFAS from drinking water. Environ Int 136: 105446. 10.1016/j.envint.2019.105446.31926437
Xu, Z; Du, B; Wang, H; Li, Z; Wu, Y; Wang, Q; Niu, Y; Zhang, Q; Sun, K; Wang, J; Chen, S. (2023b). Perfluoroalkyl substances in umbilical cord blood and blood pressure in offspring: A prospective cohort study. Environ Health 22: 72. 10.1186/s12940-023-01023-5.37858165
Yang, J; Wang, H; Du, H; Xu, L; Liu, S; Yi, J; Qian, X; Chen, Y; Jiang, Q; He, G. (2019). Factors associated with exposure of pregnant women to perfluoroalkyl acids in North China and health risk assessment. Sci Total Environ 655: 356–362. 10.1016/j.scitotenv.2018.11.042.30471604
Yang, L; Ji, H; Liang, H; Yuan, W; Song, X; Li, X; Niu, J; Shi, H; Wen, S; Miao, M. (2022). Associations of perfluoroalkyl and polyfluoroalkyl substances with gestational hypertension and blood pressure during pregnancy: A cohort study. Environ Res 215: 114284. 10.1016/j.envres.2022.114284.36088993
Yao, J; Pan, Y; Sheng, N; Su, Z; Guo, Y; Wang, J; Dai, J. (2020). Novel perfluoroalkyl ether carboxylic acids (PFECAs) and sulfonic acids (PFESAs): Occurrence and association with serum biochemical parameters in residents living near a fluorochemical plant in China. Environ Sci Technol 54: 13389–13398. 10.1021/acs.est.0c02888.33047597
Yao, Q; Gao, Y; Zhang, Y; Qin, K; Liew, Z; Tian, Y. (2021). Associations of paternal and maternal per- and polyfluoroalkyl substances exposure with cord serum reproductive hormones, placental steroidogenic enzyme and birth weight. Chemosphere 285: 131521. 10.1016/j.chemosphere.2021.131521.34273704
Yao, W; Xu, J; Tang, W; Gao, C; Tao, L; Yu, J; Lv, J; Wang, H; Fan, Y; Xu, DX; Huang, Y. (2023). Developmental toxicity of perfluorohexane sulfonate at human relevant dose during pregnancy via disruption in placental lipid homeostasis. Environ Int 177: 108014. 10.1016/j.envint.2023.108014.37315490
Yao, Y; Vehtari, A; Simpson, D; Gelman, A. (2017). Using stacking to average bayesian predictive distributions. Bayesian Analysis 2017.
Ye, WL; Chen, ZX; Xie, YQ; Kong, ML; Li, QQ; Yu, S; Chu, C; Dong, GH; Zeng, XW. (2021). Associations between serum isomers of perfluoroalkyl acids and metabolic syndrome in adults: Isomers of C8 Health Project in China. Environ Res 196: 110430. 10.1016/j.envres.2020.110430.33181135
Yeung, LW; Guruge, KS; Taniyasu, S; Yamashita, N; Angus, PW; Herath, CB. (2013). Profiles of perfluoroalkyl substances in the liver and serum of patients with liver cancer and cirrhosis in Australia. Ecotoxicol Environ Saf 96: 139–146. 10.1016/j.ecoenv.2013.06.006.23849467
Yin, X; Di, T; Cao, X; Liu, Z; Xie, J; Zhang, S. (2021). Chronic exposure to perfluorohexane sulfonate leads to a reproduction deficit by suppressing hypothalamic kisspeptin expression in mice. Journal of Ovarian Research 14: 141. 10.1186/s13048-021-00903-z.34706750
Yu, Y; Qin, XD; Bloom, MS; Chu, C; Dai, X; Li, QQ; Chen, ZX; Kong, ML; Xie, YQ; Meng, WJ; Yang, BY; Hu, LW; Zeng, XW; Zhao, XM; Zhou, Y; Dong, GH. (2022). Associations of prenatal exposure to perfluoroalkyl substances with preterm birth: A family-based birth cohort study. Environ Res 214: 113803. 10.1016/j.envres.2022.113803.35810818
Yun, J; Kwon, SC. (2023). The Association of Perfluoroalkyl Substance Exposure and a Serum Liver Function Marker in Korean Adults. Toxics 11: 965. 10.3390/toxics11120965.38133366
Zeng, G; Zhang, Q; Wang, X; Wu, KH. (2022). The relationship between multiple perfluoroalkyl substances and cardiorespiratory fitness in male adolescents. Environ Sci Pollut Res Int 29: 53433–53443. 10.1007/s11356-022-19685-y.35288850
Zeng, X; Chen, T; Cui, Y; Zhao, J; Chen, Q; Yu, Z; Zhang, Y; Han, L; Chen, Y; Zhang, J. (2023a). In utero exposure to perfluoroalkyl substances and early childhood BMI trajectories: A mediation analysis with neonatal metabolic profiles. Sci Total Environ 867: 161504. 10.1016/j.scitotenv.2023.161504.36634772
Zeng, XW; Bloom, MS; Wei, F; Liu, L; Qin, J; Xue, L; Wang, S; Huang, G; Teng, M; He, B; Mao, X; Chu, C; Lin, S; Dong, GH; Tan, W. (2023b). Perfluoroalkyl Acids in Follicular Fluid and Embryo Quality during IVF: A Prospective IVF Cohort in China. Environ Health Perspect. 10.1289/EHP10857.
Zhang, JJ. (2022). RE: Prenatal exposure to perfluoroalkyl and polyfluoroalkyl substances and birth outcomes: A longitudinal cohort with repeated measurements.
Zhang, W; Lin, Z; Hu, M; Wang, X; Lian, Q; Lin, K; Dong, Q; Huang, C. (2011). Perfluorinated chemicals in blood of residents in Wenzhou, China. Ecotoxicol Environ Saf 74: 1787–1793. 10.1016/j.ecoenv.2011.04.027.21570120
Zhang, Y; Chen, R; Gao, Y; Qu, J; Wang, Z; Zhao, M; Bai, X; Jin, H. (2023a). Human serum poly- and perfluoroalkyl substance concentrations and their associations with gestational diabetes mellitus. Environ Pollut 317: 120833. 10.1016/j.envpol.2022.120833.36493933
Zhang, Y; Mustieles, V; Sun, Y; Oulhote, Y; Wang, YX; Messerlian, C. (2022). Association between serum per- and polyfluoroalkyl substances concentrations and common cold among children and adolescents in the United States. Environ Int 164: 107239. 10.1016/j.envint.2022.107239.35447424
Zhang, Y; Mustieles, V; Wang, YX; Sun, Q; Coull, B; Sun, Y; Slitt, A; Messerlian, C. (2023b). Red blood cell folate modifies the association between serum per- and polyfluoroalkyl substances and antibody concentrations in U.S. adolescents. Environ Sci Technol 57: 2445–2456. 10.1021/acs.est.2c07152.36715557
Zhao, X; Lin, JY; Dong, WW; Tang, ML; Yan, SG. (2022). Per- and polyfluoroalkyl substances exposure and bone mineral density in the U.S. population from NHANES 2005-2014. J Expo Sci Environ Epidemiol. 10.1038/s41370-022-00452-7.
Zhou, Y; Li, Q; Wang, P; Li, J; Zhao, W; Zhang, L; Wang, H; Cheng, Y; Shi, H; Li, J; Zhang, Y. (2023). Associations of prenatal PFAS exposure and early childhood neurodevelopment: Evidence from the Shanghai Maternal-Child Pairs Cohort. Environ Int 173: 107850. 10.1016/j.envint.2023.107850.36857906
Zhu, Y; Bartell, SM. (2022). Per- and polyfluoroalkyl substances in drinking water and hypertensive disorders of pregnancy in the United States during 2013-2015. Environmental Epidemiology 6: e209. 10.1097/EE9.0000000000000209.35702500
Zong, G; Grandjean, P; Wang, X; Sun, Q. (2016). Lactation history, serum concentrations of persistent organic pollutants, and maternal risk of diabetes. Environ Res 150: 282–288. 10.1016/j.envres.2016.06.023.27336232