# APPENDIX G RESPONSE TO PUBLIC AND EXTERNAL PEER REVIEW COMMENTS AND EPA’S DISPOSITION

The Toxicological Review of Perfluorohexanesulfonic Acid and Related Salts has undergone a formal external peer review in accordance with the U.S. Environmental Protection Agency (EPA) guidance on peer review (U.S. EPA, 2015). A public, external peer review meeting was held February 26, 27 and March 1, 2024, which included an opportunity for public comment. The external peer reviewers were tasked with providing written answers to general questions on the overall assessment approach, key conclusions, and areas of scientific controversy or uncertainty. Prior to the external review, the Toxicological Review of Perfluorohexanesulfonic Acid and Related Salts was released for public comment (in July 2023). Public comments on the assessment were submitted to the U.S. Environmental Protection Agency (EPA) docket (https://www.regulations.gov/docket/EPA-HQ-ORD-2021-0562 (https://gcc02.safelinks.protection.outlook.com/?url=https%3A%2F%2Fwww.regulations.gov%2Fdocket%2FEPA-HQ-ORD-2021-0562&data=05%7C02%7CDruwe.Ingrid%40epa.gov%7C3475f0fa494e46e99f6208dcf81be5ab%7C88b378b367484867acf976aacbeca6a7%7C0%7C0%7C638658045899730862%7CUnknown%7CTWFpbGZsb3d8eyJWIjoiMC4wLjAwMDAiLCJQIjoiV2luMzIiLCJBTiI6Ik1haWwiLCJXVCI6Mn0%3D%7C0%7C%7C%7C&sdata=A3stu3HTCEdc5fZZ%2FXxszjogGbFuSNElZwxkjw4efHE%3D&reserved=0)) by September 22, 2023.

Comments made by the external peer reviewers and public comments submitted to the EPA docket, as well as EPA’s responses to these comments, are arranged by charge question below. In addition, each charge question includes an overarching summary of the peer-review panel’s comments, drawing from the summary language provided in Section 2 of the final peer-review report. In many cases, the comments of the individual reviewers have been synthesized and paraphrased for brevity but when feasible this appendix uses direct language from the external peer-review report and public comments (please consult the final peer-review report for the full text of the panel’s comments and consult the EPA docket for the full text of the public comments received (https://www.regulations.gov/docket/EPA-HQ-ORD-2021-0562 (https://gcc02.safelinks.protection.outlook.com/?url=https%3A%2F%2Fwww.regulations.gov%2Fdocket%2FEPA-HQ-ORD-2021-0562&data=05%7C02%7CDruwe.Ingrid%40epa.gov%7C3475f0fa494e46e99f6208dcf81be5ab%7C88b378b367484867acf976aacbeca6a7%7C0%7C0%7C638658045899730862%7CUnknown%7CTWFpbGZsb3d8eyJWIjoiMC4wLjAwMDAiLCJQIjoiV2luMzIiLCJBTiI6Ik1haWwiLCJXVCI6Mn0%3D%7C0%7C%7C%7C&sdata=A3stu3HTCEdc5fZZ%2FXxszjogGbFuSNElZwxkjw4efHE%3D&reserved=0)). External peer reviewers were asked to prioritize their comments to indicate their relative importance as follows. The prioritization instructions are duplicated below from the IRIS PFHxS charge questions to the peer reviewers, which can be found on the IRIS website (https://iris.epa.gov/document/&deid=358273 (https://iris.epa.gov/document/%26deid=358273)) and in the public EPA docket.

- Tier 1: Necessary Revisions – Use this category for any revisions you believe are necessary to adequately support and substantiate the analyses or scientific basis for the assessment conclusions.
- Tier 2: Suggested Revisions – Use this category for any revisions you encourage EPA to implement to strengthen the analyses or scientific basis for the assessment conclusions, or to improve the clarity of the presentation in the PFHxS Toxicological Review.
- Tier 3: Future Considerations – Use this category for any advice you have for scientific exploration that might inform future work. While these recommendations are generally outside the immediate scope or needs of the PFHxS Toxicological Review, they could inform future reviews or research efforts.

Appendix G includes responses to all Tier 1 Necessary Revisions (“Recommendations”), Tier 2 Suggestions, and Tier 3 Future Considerations from the external peer reviewers, organized by charge question. Within each tier, for each charge question, the comments are numbered to facilitate cross-referencing. Tier 1 Recommendations and Tier 2 Suggestions were considered in light of the extent to which those suggestions would impact the conclusions or quantitative analyses of the assessment, consistency across committee members in raising the suggestion, and the level of effort to implement. For this assessment, all Tier 1 and Tier 2 comments deemed impactful to the toxicity value conclusions have been fully addressed, with the majority of recommendations implemented in the final assessment. Tier 3 Future Considerations are generally outside the immediate scope or need of the Toxicological Review but may inform future analyses. All of the Tier 3 considerations received from peer reviewers on this assessment were addressed or implemented; these comments ultimately did not inform the analyses in this assessment but are listed along with the Tier 1 and Tier 2 comments for completeness. Text from the report that could be interpreted as advice or suggestions to EPA, but which was not tiered, was considered by EPA as Tier 3.

Public comments made on topics raised by the external peer reviewers are noted along with the external peer-review comments. When comments from the public and peer-review panel on a topic conflicted, the recommendations of the panel are prioritized. Additional public comments not raised by the peer reviewers are included in a separate section at the end of each charge question section.

External peer-review and public comments regarding requests for additions of clarifying text or editorial or grammatical corrections have been made throughout the assessment as appropriate; these comments and responses have not been tracked in this appendix. The complete set of public comments is available on the docket at http://www.regulations.gov [EPA-HQ-ORD-2021-0562].

## G.1 CHARGE QUESTION 1- LITERATURE SEARCH METHODS AND DOCUMENTATION

1) The Toxicological Review for PFHxS describes and applies a systematic review protocol for identifying and screening pertinent studies. The protocol is described in brief detail in Section 1.2.1 (Literature Searching and Screening) and in full detail in Appendix A (Systematic Review Protocol for the PFAS IRIS Assessments).
  a. Comment on whether the literature search strategy and screening criteria for PFHxS are appropriate and clearly described.
  b. Identify additional peer-reviewed studies of PFHxS that EPA should consider incorporating prior to finalizing the assessment.
  c. Review EPA’s characterization and provide tiered recommendations regarding which studies, if any, would have a material impact on the draft’s conclusions and should be incorporated into the assessment before finalizing, as well as your interpretation of the impact of those studies to be incorporated.

### G.1.1 External Peer Review Comments on Charge Question 1a

#### Peer Review Comment Summary

While several Tier 1, Tier 2, and Tier 3 comments were provided, all nine reviewers agreed that the literature search strategy and screening criteria were appropriate and clearly described. The tiered comments on Charge Question 1a were:

- 5 Tier 1 Recommended Revisions from 3 panelists (2 panelists each had 2 comments)
- 5 Tier 2 Suggested Revisions from 4 panelists
- 2 Tier 3 Future Considerations from 2 panelists

#### Tier 1 Recommended Revisions

[underlined: Tier 1 Recommendation 1 of 5]: One peer reviewer observed “Carefully edit and update the Background Information section with correct estimates of parameters and up-to-date references; furthermore, include basic summary information on temporal trends of distributions of population serum PFHxS levels (e.g., using data from multiple NHANES periods for the US).

[underlined: EPA Response]: IRIS assessments provide contextual information on exposure information as part of the Background section. The information is not intended to be comprehensive because it’s beyond the scope of the IRIS Toxicological Review. EPA has confirmed that the citations are reasonably recent and consistent with other recently finalized IRIS PFAS assessments, i.e., PFDA, PFHxA, PFBA (U.S. EPA, 2021b, 2023a, b).

[underlined: Tier 1 Recommendation 2 of 5]: The same reviewer recommended “including values of PFHxS properties that are critical to its pharmacokinetics in Table 1-1.”

[underlined: EPA Response]: Table 1-1 in the Background section presents summary information on physical-chemical parameters (e.g., as can be located in EPA’s CompTox Chemicals Dashboard for any chemical), not the results of the assessment’s analysis of the available PK and toxicological data Rather, Table ES-1 provides a summary of the health effects data resulting from EPA’s analysis while Table 3-6 in Section 3.1.6, Empirical Pharmacokinetic Analyses, is a PK summary table that incorporates new parameters developed during the course of assessment development. Therefore, to help bridge the introductory material with the PK results, a footnote was added to Table ES-1 with links to the PK parameter summary table (3-6) and the section where it appears.

[underlined: Tier 1 Recommendation 3 of 5]: A reviewer recommended “specifying that human epidemiological studies are only included for potential use in quantitative dose-response assessment if people were only exposed to the single PFAS of interest.”

[underlined: EPA Response]: EPA guidelines outline a preference for well-conducted human studies for derivation of toxicity values when available. The following quote is from the EPA cancer guidelines (2005) but similar language exists in EPA noncancer guidelines and it applies equally well to cancer and noncancer toxicity value derivation: “Epidemiologic data are extremely valuable in risk assessment because they provide direct evidence on whether a substance is likely to produce cancer in humans, thereby avoiding issues such as: species-to-species inference, extrapolation to exposures relevant to people, effects of concomitant exposures due to lifestyles. Thus, epidemiologic studies typically evaluate agents under more relevant conditions. When human data of high quality and adequate statistical power are available, they are generally preferable over animal data and should be given greater weight in hazard characterization and dose-response assessment, although both can be used.” This preference for human data in toxicity value derivation is reiterated in the IRIS Handbook (U.S. EPA, 2022b).

When using epidemiologic studies for hazard identification and dose-response analysis, it is critical to evaluate and transparently document the risk of bias and the potential for insensitivity in the available studies, both at the individual study level and across the body of evidence. The systematic review framework described in the IRIS Handbook is a state-of-the-art method that has been reviewed favorably by the National Academies of Science, Engineering, and Medicine (NASEM 2020). It was developed through an extensive, decade-long engagement with the national and international systematic review community, and the public.

An often-voiced concern regarding use of epidemiologic data in PFAS human health assessments, particularly for toxicity value derivation, is the potential for confounding across PFAS. The general population is typically exposed to a variety of PFAS, and it can be difficult to disentangle the independent effect of a single PFAS, although refined evaluations of potential confounding can help. It is important to acknowledge this as a source of uncertainty in the observational epidemiology evidence, but only in conjunction with informative analyses of the likelihood and direction of potential confounding for the specific studies and populations being evaluated. It is not scientifically justified to use a generalized, hypothetical concern over possible confounding as a reason to automatically dismiss epidemiological studies of PFAS exposure, which has been suggested by some individuals even in reference to entire large databases of epidemiological evidence for some health outcomes. Rather, it is necessary to carefully consider the direct evidence on potential confounding based on established epidemiological techniques, and to transparently document these analyses and subsequent decisions for review by qualified experts.

There are standard methods in epidemiology and systematic review to evaluate the potential for confounding within individual studies and across studies. For some PFAS, there are studies in occupational populations or in communities with large water contamination events that are less susceptible to this source of confounding because a single PFAS predominates the exposure. This type of study is largely not available for PFHxS (a contamination event did occur in Ronneby, Sweden, but PFOS was a co-contaminant). Thus, in assessing the potential for confounding by other PFAS, the IRIS PFHxS assessment primarily relied on analysis of results from multipollutant modeling with adjustment for co-exposures through a variety of mixture approaches. While not all of the available studies presented this information, the results in the studies that perform multipollutant modeling can be informative for the body of evidence as a whole. There was also consideration of the correlations between PFHxS and other PFAS in the study populations. As PFAS exposure profiles differ for a variety of reasons (e.g., proximity to manufacturing), these correlations vary across populations; where correlations between PFHxS and another PFAS are low, confounding of the PFHxS results by that PFAS are of lesser concern.

For health outcomes advanced for dose-response assessment based on moderate or robust human evidence conclusions, particularly those with consistent results across different epidemiological studies with heterogeneous populations and exposure scenarios, the potential for any confounding by co-occurring PFAS was judged by EPA as unlikely to explain the identified hazards. This does not eliminate the possibility of confounding existing, and this source of uncertainty is acknowledged in the assessment. However, uncertainty is an inherent part of the risk assessment process, and, in these cases, the evidence was sufficient to reasonably rule out this uncertainty as a substantial contributor to the results. Separately, it is important to note that use of animal data instead of epidemiologic data does not eliminate uncertainty, but rather trades it for a different source (i.e., interspecies extrapolation).

For toxicity value derivation in the PFHxS assessment specifically, the outcome of vaccine response underwent this analysis, and it was determined that confounding was unlikely to explain the observed effects, and further, that adjustment for other PFAS had no impact on the POD (see response for vaccine response for additional detail). In contrast, for other outcomes, such as liver enzymes and serum lipids, the potential for confounding by other PFAS was considered a greater source of uncertainty that prevented the PFHxS human evidence from reaching a judgment of moderate and thus prevented the use of these data to support toxicity values in this assessment.

[underlined: Tier 1 Recommendation 4 of 5]: Another reviewer commented “Executive Summary 1 (ES.1), Page xvi, the new chronic and subchronic oral RfD is 4 * 10−10 mg/kg/day. This level is much lower than the existing chronic RfD from NH DES (9.7 * 10^−6^ mg/kg/day) and TCEQ (3.8 * 10−6 mg/kg/day) from Table A-2 in the Appendix A document. It is understandable that these differences are partially because the selection of different critical toxicity endpoints and different critical toxicity studies. However, the reasons of these differences should be explained, so that readers have a full understanding why RfD is substantially reduced.”

[underlined: EPA Response]: IRIS assessments are independent analyses of the available evidence. This means they may arrive at different conclusions than those drawn by others. The discussion and comparison of decisions across different agencies with different decision contexts, mandates, and guidelines is outside the scope of an IRIS assessment.

[underlined: Tier 1 Recommendation 5 of 5]: This reviewer also commented “recommended reconciling duplicate references in the HERO site.”

[underlined: EPA Response]: HERO is updated and references deduplicated frequently. EPA has gone through the identified duplicates and removed them from the PFHxS HERO project page.

#### Tier 2 Suggested Revisions

[underlined: Tier 2 Suggestion 1 of 5]: A panelist observed “In Section 2.2 study evaluation results were described in more detail. In some cases, the difference between the number of studies listed in Figure 2-1 were different when specific study results are listed in Section 2.2., which to be expected; however, some cases the number of studies was difficult to track. For example, the first sentence under Section 2.2 lines 1-2 states that “one hundred seventeen epidemiologic studies were identified that met the PECO criteria and report on the potential association between PFHxS and human health effects.” For the reader it is unknown what happened to the other studies in the initial N = 415 human health effects studies identified in the literature search. A Tier 2 suggested revision would be to add 2 to 3 sentences that provide a few comments on the non-PECO studies? Did these contain primarily duplicate studies, studies of poor quality, etc.? This would help to increase the clarity of report and provide a link between the numbers listed in Figure 2-1 and the studies selected in Section 2.2. (Note that this is in strong contrast to the very detailed and helpful characterization of EPA for the characterization of the studies identified after the public release of the IRIS document.)

[underlined: EPA Response]: EPA notes that the 117 number was an error and has been corrected to 415 human health effects studies identified.

[underlined: Tier 2 Suggestion 2 of 5]: Another panelist suggested EPA “include references to documents (and online portals) relevant to PFHxS risk characterizations that have been developed by US and international regulatory agencies; compile a summary (e.g., in the form of a table) of established or proposed values for metrics of reference doses/concentrations if such metrics are identified. [underlined: EPA Response]: Please see Appendix A Table A-2 in http://cfpub.epa.gov/ncea/irisdrafts/recordisplay.cfm?deid=345065 (http://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=345065). and the EPA Response to Charge 1a Tier 1 Comment 4 of 5 above.

[underlined: Tier 2 Suggestion 3 of 5]: This panelist also recommended that EPA “incorporate a separate a section summarizing and organizing available mechanistic information on mechanistic studies of PFHxS biochemical properties (such as binding affinities to serum proteins renal transporters, PPAR); ideally present this information in a manner that allows comparisons of these properties across multiple PFAS.”

[underlined: EPA Response]: The current assessment presents the mechanistic information on PFHxS in Section 3.2.10 and summarizes the serum binding properties in “Distribution in Blood/Proteins” within Section 3.1.2 An additional section re-presenting this information together was not added.

[underlined: Tier 2 Suggestion 4 of 5]: A panel member commented that “animal studies that used historical controls should be excluded under the PECO criteria, which would strengthen the confidence of the outcomes if only concurrent non-exposed groups were compared.”

[underlined: EPA Response]: No studies using historical controls were identified in the literature search for PFHxS, so this issue did not impact the current assessment. However, while concurrent controls are strongly preferred, EPA disagrees that studies using historical controls should always be excluded. For example, historical controls can be useful in the evaluation of rare tumors or when considering the similarity between current experimental animals and laboratory conditions to historical controls. That said, use of historical controls only would be noted as a limitation during study evaluation, so concurrent and historical controls are not considered equal.

[underlined: Tier 2 Suggestion 5 of 5]: Another panel member had a similar comment, “Table 1-4 includes a description of PECO criteria, and this language is necessarily general. However, the description of comparators including to historical controls is not valid for serum hormone measurements. Therefore, it would seem appropriate to refine the description to specify when concordant or historical controls should be required for the PECO analysis.”

[underlined: EPA Response]: Please see the EPA Response to Charge 1a Tier 2 Suggestion 4 of 5 immediately above.

#### Tier 3 Future Considerations

[underlined: Tier 3 Future Consideration1 of 2]: A panelist commented that EPA “develop a plan for the systematic and regular (continuous or periodic) updating, as well as the evaluation of the consistency, of the information available through the HERO and HAWC portals relevant to the Toxicological Review(s); furthermore, specify criteria for new information that would require re-evaluation of the PFAS Toxicological Review(s).”

[underlined: EPA Response]: A decision to launch an updated IRIS assessment depends on important programmatic factors and resource availability. Given the finite resources of the IRIS Program, IRIS assessment activities are based on the priority needs of EPA National Program and Regional Offices identified through an internal process. Importantly, the availability of new scientific information does not necessarily mean that existing IRIS toxicity values are outdated or not based upon the best available science.

To address the long-term assessment needs for PFAS, EPA has developed a chemical category approach with the goal for application to PFAS so that these will be able to be readily characterized by a chemical structure (Patlewicz et al., 2022). In addition, EPA has developed systematic evidence maps (SEM) to collect and inventory the current data on thousands of PFAS (Shirke et al., 2024; Radke et al., 2022; Carlson et al., 2022). The SEM inventory the available toxicity data across broader classes of PFAS in parallel with tiered toxicity testing. The SEMs highlight data gaps and fit-for-purpose assessment opportunities for emerging PFAS of concern (Shirke et al., 2024; Radke et al., 2022; Carlson et al., 2022). EPA has also partnered with the National Institute of Health (NIH) to develop tiered toxicity testing strategies to fill data gaps and inform decisions on grouping and prioritization (https://www.epa.gov/sites/default/files/201902/documents/pfasactionplan021319508compliant1.pdf (https://www.epa.gov/sites/default/files/201902/documents/pfas_action_plan_021319_508compliant_1.pdf)). These ongoing parallel efforts within EPA are separate from the IRIS PFAS assessments, and all are interlinked components of EPA’s PFAS Strategic Roadmap (PFAS Strategic Roadmap: EPA’s Commitments to Action 2021-2024 | US EPA (https://www.epa.gov/pfas/pfas-strategic-roadmap-epas-commitments-action-2021-2024)).

[underlined: Tier 3 Future Consideration 2 of 2]: Another panelist commented “The literature search dates may need to be updated. On Page 1-8, it says the most recent literature search update that was fully incorporated into the assessment is from April 2022, but in the Appendix A (Page 4-2), it still says February 2018. The dates should be updated.”

[underlined: EPA Response]: The document the reviewer is referencing is Appendix A of the PFAS protocol published by EPA in 2019 (U.S. EPA, 2019b) and not the supplemental information on the literature searches for PFHxS. There was a typographical error in the above statement as the most recent literature search update that was fully incorporated into the assessment is from April 2023, not April 2022. The document has been corrected to reflect the correct date: April 2023. For the PFHxS assessment, Appendix B.3 titled “Documentation of literature search updates after April 2023” presents the information on literature search updates and is in accord with the text in the main document.

### G.1.2 External Peer Review Comments on Charge Question 1b

#### Peer Review Comment Summary

Four of the reviewers did not identify any additional studies of PFHxS for EPA to consider prior to finalizing the assessment. The remaining reviewers provided specific comments on additional studies for EPA to consider incorporating, either as described below or, for one commenter, under the health effect-specific charge questions (see Section G.2). The tiered comments on Charge Question 1b were:

- 3 Tier 1 Recommended Revisions from 1 panelist
- 6 Tier 2 Suggested Revisions from 2 panelists (the panelist that provided all the Tier 1 comments provided 5 of the 6 Tier 2 comments)
- 2 Tier 3 Future Consideration

#### Tier 1 Recommended Revisions

[underlined: Tier 1 Recommendation 1 of 3]: One panel member provided all three Tier 1 comments on charge question 1b. First, they recommended “reviewing the literature on amenorrhea among nulliparous women as well as hormonal contraception use, which can reduce or stop menstrual flow and using this information to inform the PBPK model.”

[underlined: EPA Response]: EPA notes that a PBPK model is not being used to evaluate human dosimetry. The document has been revised (Section 3.1.4, sub-section on Sex differences in human PFHxS PK) to state that women may be amenorrheic or have reduced menstrual flow for a variety of reasons, including amenorrhea due to elite athleticism and reduced menstrual flow due to contraceptive use. However, a quantitative analysis of the distribution of menstrual fluid excretion among women is not possible with the available science. Instead, it is noted that the estimated difference in average clearance among men vs. women, which is associated with menstruation, appears to be less than a factor of 2, i.e., less than the factor of 3 considered to represent inter-individual variability in PK among the human population (the PK -based contribution to the UFH = intraspecies uncertainty factor). Therefore, use of this factor in the assessment is expected to provide RfD values that are sufficiently protective for developmental effects in children of women who are completely amenorrheic prior to becoming pregnant. Since the adjustment for menstrual-associated clearance is only used in the evaluation of developmental effects and not for other effects such as those on the thyroid in adults, those candidate values effectively apply the health-protective assumption that women of childbearing age are completely amenorrheic.

[underlined: Tier 1 Recommendation 2 of 3]: This panel member also recommended that EPA “add studies on reproductive and immune effects in mice.”

[underlined: EPA Response]: Several studies were provided by panel members and public commenters. These studies were evaluated for inclusion using the using the PECO criteria described in Section 1.2.1 and Table 1.4. As described in the PFHxS charge questions, after public release of a draft assessment, studies are typically only integrated into the assessment if the study is likely to impact conclusions (i.e., identified hazards or toxicity values). Appendix B, Table B-5 provides EPA’s characterization for all such newly identified studies. The studies identified by the reviewer have been added to Table B-5 in Appendix B of the revised assessment. One of the two studies, (Weatherly et al., 2024) was tagged as supplemental (non-PECO route of exposure) and the other (Narizzano et al., 2023) was not integrated into the main assessment because it was not considered impactful to hazard or toxicity value conclusions.

[underlined: Tier 1 Recommendation 3 of 3]: A third comment from this panelist recommended EPA “add quality cancer studies.”

[underlined: EPA Response]: The recommended cancer studies were reviewed by EPA for impact on the carcinogenicity assessment, as described in the charge questions. Since these studies were generally null or inconsistent and limited to one or a few studies on each specific cancer types, they did not influence the carcinogenicity conclusion or the ability to derive cancer toxicity values and thus were not incorporated into the evidence synthesis and integration text. However, a footnote was added to point readers towards the newly identified studies which are summarized in Appendix B, Table B-5.

#### Tier 2 Suggested Revisions

[underlined: Tier 2 Suggestion 1 of 6]: The panelist providing all the Tier 1 comments on charge question 1b also provided 5 of the 6 Tier 2 comments. This panelist suggested EPA “Include summary of breast milk and infant formula as an important exposure pathway.”

[underlined: EPA Response]: Breast milk and baby formula are described as potential sources of exposure in infants in Sections 1.1.4 and 3.1.2 of the revised Toxicological Review.

[underlined: Tier 2 Suggestion 2 of 6]: This panelist also commented “EPA should consider adding information on contaminated drinking water as a source of exposure.”

[underlined: EPA Response]: Human exposure to PFHxS in drinking water is included and described in Section 1.1.4 as part of the background section of the revised Toxicological Review.

[underlined: Tier 2 Suggestion 3 of 6]: The same reviewer suggested EPA “add studies on inhalation and dermal exposure.”

[underlined: EPA Response]: No inhalation studies of PFHxS were identified. As outlined in the Systematic Review Protocol for the PFBA, PFHxA, PFHxS, PFNA, and PFBA assessments published by EPA (https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=345065#tab-1), dermal studies fall outside of the scope of the IRIS PFAS assessments; however, such studies were also not available.

[underlined: Tier 2 Suggestion 4 of 6]: This reviewer further encouraged EPA to “add studies on lactation duration.”

[underlined: EPA Response]: Section 3.2.8 has been added in the revised assessment to address breastfeeding duration studies.

[underlined: Tier 2 Suggestion 5 of 6]: Relatedly, this reviewer also commented that EPA should “add studies on bone mineral density and osteoporosis.”

[underlined: EPA Response]: Section 3.2.11, other noncancer effects, has been expanded to address bone mineral density and osteoporosis studies.

[underlined: Tier 2 Suggestion 6 of 6]: Another panelist commented “The following are papers listed in PubMed since March 2023 that relate to PFHxS and thyroid. There appear to be enough interest in this toxicant that EPA should perform a final search and review before completion. Also, because the thyroid endpoint was evaluated but not used in the overall analysis, finding a few new studies may change the Agency’s analysis on this endpoint.”

[underlined: EPA Response]: The suggested additional studies have been considered and added to Appendix B Table B-5 in the revised assessment. Given the inconsistency of the evidence already evaluated in the assessment and that the studies shared by the commenter were either already evaluated in the assessment, did not provide new information, or did not have any impact on the interpretation and characterization of this endpoint, these studies were not incorporated into the synthesis text.

#### Tier 3 Future Considerations

[underlined: Tier 3 Future Consideration 1 of 2]: A panelist commented: “Future documents, EPA might as the strategy question with a caveat that possible missing articles are to be saved for the specific section. Please consider placing its literature search question in each section, and not as a separate question. The thought is that this distribution will save reviewer time in responses and save EPA time in seeking information.”

[underlined: EPA Response]: EPA will consider this revised organization of the charge questions for future assessments.

[underlined: Tier 3 Future Consideration 2 of 2]: A panelist highlighted for EPA a brief list of recently published studies.

[underlined: EPA Response]: The list that was provided by the panelist was taken into consideration. Of the 37 studies that the panel member submitted 2 were already cited in the toxicological review, 22 studies were either not PECO relevant or were tagged as supplemental. 13 studies were tagged included and were considered for impact. None of these studies were considered impactful and were added to Appendix B Table B-5 in the revised assessment for clarity.

### G.1.3 External Peer Review Comments on Charge Question 1c

#### Peer Review Comment Summary

Three reviewers did not note any refinements to EPA’s draft approach, and another reviewer recommended EPA incorporate additional studies but agreed there was no material impact of the new studies on the draft’s conclusions. Two other reviewers provided Tier 2 suggestions to incorporate additional studies for completeness but did not speak specifically to their interpretation of the impact of those studies, while a third additional reviewer did not comment on new studies, but recommended EPA clarify their approach to interpreting thyroid hormone results. The remaining two reviewers provided several Tier 1 and Tier 2 comments to include additional studies; one provided recommendations related to immune function cancer, while the second focused on the organization of the hepatic and cardiometabolic section and recommended EPA more formally review several other, less well studied health effects. The tiered comments on Charge Question 1c were:

- 13 Tier 1 Recommended Revisions from 5 panelists (1 panelist had 8 comments and a second panelist had 2 comments)
- 7 Tier 2 Suggested Revisions from 3 panelists (the panelist that provided 8 of the Tier 1 comments had 4 Tier 2 comments; another panelist had 2 comments)
- 4 Tier 3 Future Considerations from 2 panelists (1 panelist had 3 comments)

#### Tier 1 Recommended Revisions

[underlined: Tier 1 Recommendation 1 of 13]: A panel member recommended that Narizzano et al. (2023) and Weatherly et al. 2024 be incorporated into the PFHxS Toxicological Review. Panel member commented the “[these] new studies on reproductive and immune effects of PFHxS in mice; both indicate a direct link between PFHxS and decreased functional immunity in an animal model, and therefore add experimental findings to the weight of evidence for immune function.”

[underlined: EPA Response]: Results from Narizarro et al., 2023 do not influence draft judgments or provide insights into key science issues, nor do they provide additional insights into potential mechanisms of PFHxS-induced effects; therefore, this study was not integrated into the revised draft assessment. Weatherly et al., 2024 did not meet PECO criteria as outlined in the protocol document (EPA, 2019). Further the results presented in this study do not influence draft judgments or provide insights into key science issues, nor do they provide additional insights into potential mechanisms of PFHxS-induced effects. However, both of these studies were added to Table B.5 in Appendix B for clarity.

[underlined: Tier 1 Recommendation 2 of 13]: In line with their comments under Charge 1b, the same peer reviewer also recommended that EPA “add several of the newer high quality cancer studies would indicate that PFHxS may cause testicular, thyroid, and other cancers in humans.”

[underlined: EPA Response]: The suggested cancer studies (Winquist et al., 2023; Shearer et al., 2021;Purdue et al., 2023; Moon and Mun, 2024; Madrigal et al., 2024; Li et al., 2023c) were reviewed for impact on the carcinogenicity assessment. In summary there were inconsistent results across the new studies for cancer risk. As the new studies were not interpreted to impact conclusions, they were not incorporated into the evidence synthesis and integration text. However, a footnote was added in the revised assessment to point readers towards the newly identified studies in Table B.5 in Appendix B.

[underlined: Tier 1 Recommendations 3, 4, and 5 of 13]: One panelist provided eight of the 13 Tier 1 recommendations on charge 1c (comments #3 – 10). First, the reviewer commented “There are domains that either have synthesis problems of interpretation that could benefit from additional consideration such as liver and cardiovascular. These topics overlap because the disrupted sterol metabolism, which characterizes long half-life PFAS including PFHxS occurs to a very large degree in the liver, not in the heart, has deleterious cholesterol changes as one of several outcomes. This disrupted cholesterol metabolism can then affect the heart, but the consistent findings are not evidence of toxicity occurring in the heart.” (Comment 3)

Similarly, the reviewer commented “EPA should rearrange how it approaches cholesterol.” (Comment 4)

They also recommended that “cholesterol should be approached from the perspective of liver effects.” (Comment 5)

[underlined: EPA Response]: The liver and cardiovascular sections were updated to include a detailed description of PFHxS-induced alterations of lipids in liver tissue and in serum. For the synthesis of fatty liver effects, the hepatic effects chapter was reorganized to include a stand-alone section presenting the available evidence on hepatic tissue levels of lipids and cholesterol. As outlined in the IRIS PFAS Systematic Review protocol and retained in the revised PFHxS assessment, serum lipid findings are primarily discussed as part of characterizing cardiometabolic effects as they are considered established markers of cardiovascular disease (Fryar et al., 2012; Fruchart et al., 2004;American Heart Association, 2022), while noting the importance of these outcomes in the section characterizing hepatic effects. This approach of having the primary discussion of serum lipid effects appear as part of cardiometabolic outcomes makes the PFHxS assessment consistent with other recent IRIS assessments, including of other PFAS.

[underlined: Tier 1 Recommendation 6 of 13]: This panelist also commented that “Alkaline phosphatase and bilirubin levels should not be seen as negating more specific and sensitive biomarkers.”

[underlined: EPA Response]: The synthesis in the liver and cardiovascular effects section was updated in response to this recommendation and clarify the interpretation of fatty liver and serum lipids/cholesterol. For the synthesis of fatty liver effects, the hepatic effects chapter was reorganized to include a stand-alone section presenting the available evidence on hepatic tissue levels of lipids and cholesterol. The primary analysis of serum lipids/cholesterol are described in the cardiometabolic effects chapter (see 3.2.6.). EPA respects the reviewer comments on the merit of considering cholesterol as a primarily a hepatic related outcome. However, cholesterol, serum lipids, and triglycerides are also pertinent to cardiovascular health and considered established risk factors for cardiovascular diseases including atherosclerosis, coronary heart disease, myocardial infraction, and stroke (Gad, 2015; Fruchart et al., 2004; American Heart Association, 2022). The IRIS Program’s preferred approach is to have serum lipid findings primarily discussed as part of characterizing cardiometabolic effects, while noting the importance of these outcomes in the section characterizing hepatic effects. New language was added in Sections 3.2.4 and 3.2.6 of the revised assessment to be more explicit linking hepatic effects and changes in cholesterol.

[underlined: Tier 1 Recommendations 7 and 8 of 13]: The reviewer expanded on comments related to the hepatic effects synthesis, recommending that “EPA make better use of the “Hill criteria” for 360 considerations and more careful use of Hall criteria, consistent with the original article and its advice including when Hall criteria do not apply.” (Comment 7)

They similarly recommended “that application of Hall toxicology criteria to dismiss presumed adaptive responses is inappropriate when the exposure of interest is not short term in humans, and when there is evidence of human toxicity in the domain of (supposed) animal adaptive response.” (Comment 8)

[underlined: EPA Response]: Section titled “Considerations for potentially adaptive versus adverse responses” where the Hall criteria is discussed was updated in response to comments and recommendations of the interpretation of serum markers of liver disease and hepatic lipid and cholesterol accumulation.

EPA retains use of the Hall considerations (Hall et al., 2012) to aid evaluations (e.g., of adversity) of the hepatic effects evidence in the revised PFHxS Toxicological Review. This approach was outlined in the PFAS Protocol and is consistent with other IRIS Toxicological Reviews of PFAS. After a re-analysis of the available evidence and consideration of the strengths and weaknesses of the available studies, the revised assessment retains the conclusions that the available animal and human evidence provide slight evidence for hepatic effects, and the evidence integration summary judgment remains that the evidence suggests, but is not sufficient to infer, that exposure to PFHxS might causes hepatic system effects in humans. Although a likely health hazard was not identified (IRIS assessments typically do not include dose-response analyses for hazards with an evidence suggests evidence integration conclusion (U.S. EPA, 2022b)), a POD was calculated for hepatic effects because the evidence base for PFHxS includes well conducted epidemiological studies, PODs for these outcomes were considered informative of the magnitude of effects relevant to susceptible lifestages and populations, and the POD was considered potentially informative to decisions regarding the better-supported values (e.g., comparing PODs to inform uncertainty factor selection) or for potential future use in other decision contexts (e.g., providing a sense of the uncertainty of potential risks, ranking potential hazards, or setting research priorities) (U.S. EPA, 2005).

[underlined: Tier 1 Recommendation 9 of 13]: The panel member also commented “that there is sufficient information to consider bone metabolism/osteoporosis as an outcome.”

[underlined: EPA Response]: Section 3.2.11. has been expanded to include a discussion of bone mineral density studies.

[underlined: Tier 1 Recommendation 10 of 13]: Lastly, this reviewer commented “Update references.” (and provided a list of references to EPA)

[underlined: EPA Response]: The list of references provided was screened against the PECO criteria and studies meeting PECO were evaluated for their impact on the assessment conclusions, as previously described. These studies and EPA’s disposition on these studies were added to Table B-5 in Appendix B of the revised assessment. Studies were not incorporated for various reasons but namely because this list included a number of references that were not PECO relevant (e.g., not PFHxS studies), supplemental (e.g., reviews and background references), or would not change the draft judgment or inform dose response.

[underlined: Tier 1 Recommendation 11 of 13]: A separate panel member recommended EPA “Confirm that the new references cited in the reviewer pre-comments are indeed listed and described to use in an expanded table of reference providence.”

[underlined: EPA Response]: EPA verified that the reviewer pre-comment references were considered and added to table B-5 in Appendix B of the revised assessment.

[underlined: Tier 1 Recommendation 12 of 13]: Another panelist recommended that “EPA should evaluate whether animal studies such as Adyenni et al. (2023), He et al. (2022), and Narizzano et al. (2023) and population studies such as Kim et al. (2023) and Xu et al. (2023) meet PECO criteria (see also comment in 1b).”

[underlined: EPA Response]: EPA reviewed the references listed against the assessment PECO criteria and in light of their potential to impact assessment conclusions, as previously described. The studies were ultimately added to Table B-5 in Appendix B of the revised assessment for clarity because they were not considered to impact existing hazard or dose-response conclusions.

[underlined: Tier 1 Recommendation 13 of 13]: A peer reviewer commented “In Table B-5 of Appendix B under Endocrine, it seems reasonable to conclude that the reviewed studies would not alter the conclusions of the PFHxS review. However, in the Results Summary for Jensen et al. (2022), it states “No association with free T4, positive but non-monotonic and not statistically significant association with TSH….” This seems to imply that the Agency discounts non-monotonic associations as a matter of policy. If this is the policy, that policy should be referenced. If it is not an official policy, the statement about non-monotonicity should be deleted. Likewise, in the Results Summary for Derakhshan et al. (2022), it says that there is a “Positive association with free T4…but no association with TSH or free T3.” This implies that “discordant” findings between associations with T4 (total or free) and TSH and/or T3 are disregarded. While the positive association is perplexing and inconsistent with other studies in humans and in rodent studies, it is a common observation for various PFAS that effects on serum T4 in rodent studies are not matched with effects on TSH, T3 or thyroid histopathology. As a result, the Results Summary here seems to contradict what is known about PFAS effects on the thyroid hormone system and is not consistent with the logic articulated in the PFHxS review. This logic is also used in Nilsson et al. (2022b). In both cases, it seems warranted to change this wording.”

[underlined: EPA Response]: EPA methods do not support an approach where non-monotonic findings are automatically discounted (e.g., see Sections 6.1 and 7.2.1 of the IRIS Handbook). The results summary in Table B-5 of the PFHxS assessment is intended as a factual statement of the results without interpretation. Thus, the mention of nonmonotonicity and lack of association in other thyroid hormones does not imply that those factors would be used to discount the findings. For both of these factors, a more detailed analysis would be required to determine how these findings would be interpreted in the context of the body of evidence. This analysis was not performed since the studies were interpreted to not alter the assessment conclusions, including the hazards identified and toxicity values derived. The text in Table B-5 was edited for clarity in an effort to address the reviewer’s concern.

#### Tier 2 Suggested Revisions

[underlined: Tier 2 Suggestion 1 of 7]: The panelist providing the majority of Tier 1 comments on charge question 1c also provided most of the Tier 2 comments (4 of 7 comments). This panelist suggested EPA “rearrange how uric acid is approached”

[underlined: EPA Response]: eGFR and uric acid findings are both presented in the kidney chapter. The synthesis was updated to discuss these two outcomes separately.

[underlined: Tier 2 Suggestion 2 of 7]: The panelist also commented “in the matter of liver disease, the document could also make use of in vitro work, showing deleterious changes.”

[underlined: EPA Response]: The liver chapter (Section 3.2.4) includes a section describing mechanistic evidence, including from in-vitro studies, and this evidence was considered for use in drawing evidence integration judgments.

[underlined: Tier 2 Suggestion 3 of 7]: On a separate topic, this peer reviewer commented “Kidney section excretion kinetics: Although the document expresses awareness of the interaction of the complex excretion kinetics with enhanced renal excretion of PFAS including PFHxS after eGFR worsens to stage 3b and beyond, and the even more marked effect when there is albuminuria, it does not make use of the knowledge and uncritically accepts outcome judgments in papers that would not pass muster now that we do understand these kinetics. There are two implications. One is for kidney disease per se as an outcome. If PFHxS causes the kidney disease then the increased clearance which occurs with disease progression could mask or dampen the true association, i.e., a causative dose-response relationship that existed prior to or early in the development of the disease would be obscured as clearance increases with the stage of disease. The other is complications of diabetes, hypertension and other diseases that commonly cause kidney disease and can do so independently of PFAS exposure. For each of these disease processes, it is near certain that underestimation bias pertains to those who have kidney disease as part of the disease process. In that circumstance, it is possible to become confused if the understanding of the complex excretion mechanics is not integrated in a convincing way to consider sources of underestimation bias for other outcomes associated with kidney disease, diabetes, or hypertension (again, because those with moderate-to-severe kidney disease or any albuminuria will be excreting more PFAS including PFHxS). In that setting, a nil or inverse (sometimes interpreted as “protective”) outcomes are sometimes uncritically accepted as causal when they are likely wholly or mostly about reverse causation. The document more consistently acknowledges/accounts for the other type of bias, the need to adjust for eGFR in the larger population who do not have moderate to severe kidney disease, in order to adjust for overestimation bias. This consideration is one part of a three-part puzzle that includes both sides of the inverted U-shaped curve of serum PFAS across the range of eGFR declines, and the lower serum PFAS with lower serum albumin (and in the presence of any albuminuria).”

[underlined: EPA Response]: A new subsection to Section 3.1.4 (Excretion) has been added, entitled, “Impact of kidney disease on urinary clearance in humans,” in which the impact of kidney disease on clearance is discussed qualitatively and which highlights the fact that kidney disease likely contributes to the observed variation in serum concentrations and clearance. However, given the variability evident in the empirical data, which results from all sources of variation and not just kidney disease as well as the lack of applicable analyses in the current literature, EPA did not include a quantitative analysis of the impact of kidney disease on overall PK variability.

[underlined: Tier 2 Suggestion 4 of 7]: The same reviewer also commented “that there is sufficient information to consider breastfeeding as an outcome.”

[underlined: EPA Response]: Section 3.2.8. has been expanded to include a discussion of the available breastfeeding duration studies.

[underlined: Tier 2 Suggestion 5 of 7]: Another panel member suggested “including new studies for fetal growth restriction to ensure balance in the assessment’s presentation of relevant evidence… If, pursuant to this Tier 2 suggested revision, EPA determines that ensuring balance as to the assessment’s presentation of relevant evidence is justified as an additional criterion for new study inclusion, then new studies with endpoint results that overall lean heavily positive or negative (e.g., fetal growth restriction) should be added to the main assessment, which would be considered a contingent Tier 2 suggestion.”

[underlined: EPA Response]: There are no instances where all the new developmental epidemiological evidence is in one direction, e.g., for several endpoints, the new data are mixed with inconsistent results within and across studies. But we generally agree with the reviewer if there was an overwhelming number of studies in one direction, and this would alter the original judgment, then the main assessment should be updated as discussed in Appendix B3.

[underlined: Tier 2 Suggestion 6 of 7]: A third peer reviewer commented “In Table B-5 of Appendix B.3, in the literature update stage of April 2023, a one-compartment PK study by Chiu et al. (2022) was incorporated into the risk assessment. Specifically, the clearance value from Chiu et al. (2022) was incorporated into the calculation of the overall average clearance. However, in a follow up study (Lynch et al. 2023) by the same group of authors published in May 2023, they reported an updated toxicokinetic model that can be used to estimate serum PFAS (including PFHxS) concentrations based on known PFAS water concentrations and physiological information. Compared to the Chiu et al. (2022) study that reported the variability of the PK parameters of PFAS for adults, the Lynch et al. study reported PK parameters for PFAS for both sexes and different age groups, including infants and children under age 6, older children and adults. This study provides specific data to inform risk assessment of PFHxS in the sensitive subpopulations of infants and children. It is suggested this new study by Lynch et al. (2023) be evaluated to see if it may be useful for the current risk assessment for PFHxS.”

[underlined: EPA Response]: Lynch et al. (2023) does not present new parameters not reported previously in the literature. (EPA has confirmed with ATSDR staff that this paper represents an application of the Chiu et al. (2022) model). More specifically, Table 1 of Lynch et al. (2023) does not report sex- or age-dependent half-lives or volumes of distribution, but only parameters from Chiu et al. (2022). The adjustment to Vd with age shown in Table 4 is already presented in the EPA’s draft review, with reference to the Goeden at al. article, cited by Lynch et al, where it was first incorporated for PFAS PK predictions. Data on lactational transfer in Table 2 are from other sources already included in EPA’s review. Table 5 of Lynch reports NHANES serum concentration data, which are not PK parameters. Lynch et al. also uses information on human BW, which depends on age and sex, but this is a model input, not an intrinsic model parameter. In summary, Lynch et al. describes an application of the Chiu et al. (2022) model, with parameters and data that were previously published, and which have already been incorporated into EPA’s assessment. Hence, EPA’s decision that the publication fails to meet EPA’s inclusion criteria is retained in the revised assessment.

[underlined: Tier 2 Suggestion 7 of 7]: This reviewer also commented “On a different note, in the PFHxS external review draft (Page 1-8) and in the charge questions above, it is said that EPA screened the literature up to March 2023, but in this charge question 1C, it indicates that EPA screened the literature up to April 2023. Please double check and make the date consistent.”

[underlined: EPA Response]: The text in the PFHxS assessment has been revised (page 1-8) to reflect the correct date of the literature review (April 2023).

#### Tier 3 Future Considerations

[underlined: Tier 3 Future Consideration 1 of 4]: A panelist commented “it would have been better if the possibility that PFHxS is a cause of kidney disease had been discussed, and it is a Tier 3 suggestion that the two interrelated topics, kidney disease per se and the effect of kidney disease on interpretation of outcomes for disease processes associated with common causes of kidney disease such as diabetes and hypertension have a place in future PFAS documents.”

[underlined: EPA Response]: EPA will consider this suggestion on the discussion of these related topics in future assessments. It is noted that this and other EPA PFAS assessments do consider the possibility of PFAS affecting kidney function to impact the interpretability of certain outcome measurements due to the possibility of reverse causation (e.g., see Section 3.2.6 on diabetes).

[underlined: Tier 3 Future Consideration 2 of 4]: Another peer reviewer “encourages USEPA to be bold in increasing the use of this [mechanistic] information as a critical component and not emphasized so much in the separate appendix sections. This information is really a key part of the review and contributes to the overall review and defines how mechanistic information is considered across specific health endpoint and how this support both the rational of choosing health impacts of interest, the consistency of such observation but also integrates methods of MOA, AOP and key characteristics into systems-based approaches which use epidemiology and in vivo animal studies as well as in vitro observations (NAMS). An essential goal for IRIS evaluations. This consideration would require a section in each health endpoint that highlights this information. Currently this is only done in some of the endpoint specific sections in Section 2. This integrative information would also be discussed in Section 4 Summary of hazard identification and conclusions.”

[underlined: EPA Response]: Mechanistic evidence analyses are performed according to assessment needs and the availability of evidence. For the PFHxS Toxicological review, mechanistic evidence was available for thyroid, immune, hepatic, and neurodevelopmental health effects. The available mechanistic evidence to inform these health hazards is discussed in the subsection titled “mechanistic evidence and supplemental information” in Sections 3.2.1, 3.2.2, 3.2.3, 3.2.4, and 3.2.5. of the PFHxS toxicological review. There was no mechanistic evidence available in the evidence base to inform cardiometabolic effects, hematopoietic effects, developmental effects, male and female reproductive effects, kidney effects, or cancer therefore a subsection titled “mechanistic evidence and supplemental evidence” was not added to the sections where PFHxS effects on the aforementioned health hazards are discussed.

[underlined: Tier 3 Future Consideration 3 of 4]: This same reviewer provided a “Future consideration to delineate the next steps for the roadmap and to include a strategy of knowledge integration building the next phase of the knowledge roadmap.”

[underlined: EPA Response]: EPA’s strategic roadmap for PFAS is periodically updated and the reviewer’s suggestion builds on goals in the current roadmap. As part of the EPA’s 2024 Strategic Roadmap “the agency is investing in research to fill gaps in our understanding of PFAS, including research to characterize the toxicity of additional PFAS and mixtures of PFAS; to study the contributions of different sources to people’s overall exposure to PFAS; and to develop methods to test, measure, remove, and destroy them.” (https://www.epa.gov/pfas/pfas-strategic-roadmap-epas-commitments-action-2021-2024).

[underlined: Tier 3 Future Consideration 4 of 4]: A third comment from this reviewer on charge question 1c was “Chapter 4 which included Table 4-1 Hazard Conclusions across published EPA PFAS human health assessments was a good start for this integration however as it contained only + and – as indicators it was limited in its ability to affect analysis. Expansion of this type of table, especially with addition of the endpoint that was identified would begin to address the cross-compound evaluations of evidence. A Tier 3 Future consideration is to add such details as an example of next steps to support the roadmap integration mentioned above.”

[underlined: EPA Response]: In lieu of expanding the table for this assessment, links have been added to the various EPA PFAS documents referenced in Table 4-1 in the footnote for interested readers to access specifics on the various health outcomes. EPA will reconsider the format of such tables in the future.

### G.1.4 Public Comments on Systematic Review and Documentation

Public Comment: Commenter (NRDC) commented: “Section 2.1; Section 2.2 -- 1. EPA’s draft toxicological assessment for PFHxS may be missing relevant health studies. In Section 2.1 Lines 6–8, EPA indicates that there are 446 studies meeting the PECO criteria, specifically 415 epidemiological studies and 20 animal studies. This is consistent with the information presented in Figure 2-1. However, the text immediately following in Section 2.2. Lines 1–6 states that there are 117 epidemiological studies and 8 animal studies meeting the PECO criteria. There is no indication as to why these values are so different, but we suspect that the information presented in Section 2.2. likely is outdated and or reflects a typographical error. HAWC, for example, indicates that 20 animal studies were included (though we note that the study by Chang et al. is probably a double entry with HAWC IDs of 100518054 and 101366633). We come to this conclusion because there are animal studies listed in HAWC as included but are not subsequently listed in Section 2.2 Lines 1–6, yet these studies are cited later in the document in Evidence Synthesis and Integration summaries in Section 3. We also note there are other studies listed in Section 2.2 that are not provided in the HAWC list of included studies. We hope that these are, in fact, typographical errors and that EPA has not improperly and without justification excluded more than half of the evidence base from further discussion. We look forward to further clarification on this important issue. In addition, we have additional concerns about studies that may have been erroneously excluded from the analysis either by excluding studies at the title and abstract level or by marking studies as “supplemental..” These concerns stem from our comparison of studies that were listed as “included” in HAWCwith studies that are currently available in the PFAS-Tox Database. The PFAS-Tox Database was built using literature searches and a PECO statement similar to that used by EPA The PFAS-Tox Database currently indicates there are 578 studies that evaluate a health or toxicological endpoints for PFHxS (literature search through January 2021); specifically, there are 449 human studies, 59 animal studies, and 71 in vitro studies.

We have included an attachment with a listing of the human studies that were included in the PFAS-Tox Database but were not tagged as included in HAWC (Worksheet labeled “PFASTox Studies Not Included” in the attachment). The attachment contains a brief summary of the endpoints that are relevant to human health (column S). We encourage peer reviewers to also review this attachment, specifically noting if there are any studies that would be of importance to the health effects that they are charged with reviewing in detail. We agree that some of the studies that were included in the PFAS-Tox Database may be out of the scope of the EPA’s analysis (for example if the only noted health effect is body mass index (BMI)). However, reviewers may be particularly interested in studies that EPA marked as supplemental, and we suggest they be checked to see whether they contain additional information on health outcomes relevant to this assessment.

We did identify one study that appeared to be marked as included by EPA, but did not have an evidence stream tag (i.e., human) applied to it, and it was therefore missing from the list of included studies we downloaded from HAWC.We discuss below other studies that may warrant additional review, either because they were marked as excluded at TIAB level or because EPA marked them as supplemental:

- An epidemiological study by Mogensen et al. (2015) that appears to have information on PFHxS and vaccine-related antibody response. An epidemiological study by Wen et al. (2019) that evaluates the association between cord plasma PFHxS and atopic dermatitis, an immune relevant endpoint.
- An experimental rodent study that investigated endpoints relevant to behavioral outcomes
- Two experimental rodent studies relevant to mechanistic hepatic effects
- Four in vitro studies have endpoints that should be evaluated for their relevance to the carcinogenicity study (DNA damage, generation of reactive oxygen species).

Additionally, a study by Buttenhoff et al. (2009), which was included by EPA, was left out of Section 3.2.2. on page 133 where animal evidence for immunotoxicity is discussed. This study describes a >28 day exposure in rats the measurement of immune relevant organs (spleen, thymus, bone marrow, lymph nodes) and discussion of this paper should be added to the immune effects section. [Please see the public comment docket for the full list of submitted references]

[underlined: EPA Response]: EPA has reviewed the details of potential errors in Section 3.1 (literature search and screening) and we believe that there is a misunderstanding on the part of the commenter. Section 3.1 and figure 2.1 list the number of identified studies meeting PECO criteria at full text level (415 epidemiological and 15 animal studies). These studies next underwent study evaluation for risk of bias. Graphical representations of outcome-specific study evaluations are presented and discussed within each of the hazard sections (see Sections 3.2.1–3.3.1). In cases for which a study was rated medium or low confidence for one or more of the evaluated outcomes, the specific limitations are explained in the synthesis section(s). Detailed rationales for each domain and overall confidence rating are available in Health Assessment Workspace Collaborative (HAWC). Please note that only evidence from PECO relevant epidemiological and animal evidence streams are extracted into HAWC. Studies with supplementary information (e.g., mechanistic studies) are currently not extracted into HAWC.

The following studies have been added to Section 3.2, Viberg et al. (2013), He et al. (2022); Yin et al. (2021), Marques et al. (2021), Tetzlaff et al. (2021), and Pfohl et al. (2020). Studies that were tagged mechanistic or supplemental were not included in this section but were referenced where appropriate in the toxicological review. 3M (2000), NTP (2018) and Chang et al. (2018) were already included in the original text in Section 3.2.

EPA identified a large overlap between the studies provided by the commenter and those identified and screened for inclusion in the assessment by EPA before April 2023. Those not already identified were screened using the PFHxS assessment PECO criteria. The results of the screening and evaluation of these studies is included in Table B.5 in Appendix B of the revised assessment. Lastly, EPA reviewed the Butenhoff et al. 2009 study and the study has now been added to Section 3.2.2 and related tables and figures in that section.

## G.2 CHARGE QUESTION 2- NONCANCER HAZARD IDENTIFICATION

2) For each health effect considered in the assessment and outlined below, please comment on whether the available data have been clearly and appropriately synthesized to describe the strengths and limitations, including whether the presentation and analysis of study results are clear, appropriate, and effective to allow for scientifically supported syntheses of the findings across sets of studies. Please comment on whether the study confidence conclusions for the PFHxS studies are scientifically justified, giving appropriate consideration to important methodological features of the assessed outcomes. Please specify any study confidence conclusions that are not justified and explain any alternative study evaluation decisions. For each, please also comment on whether the weight-of-evidence decisions for hazard identification have been clearly described and scientifically justified. Note that the data from studies considered informative to the assessment are synthesized in the relevant health effect-specific sections and available in the Health Assessment Workspace Collaborative (HAWC).
  a. For [underlined: immune effects], the Toxicological Review concludes the available evidence indicates PFHxS exposure is likely to cause immunosuppression in humans given sufficient exposure conditions, primarily on the basis of consistent evidence of reduced antibody responses from epidemiological studies in children and adults. For nearly all epidemiology studies of PFHxS, there is potential that exposure to other highly correlated PFAS could contribute to the observed effects. Thus, the synthesis of epidemiology studies on immune effects included an evaluation of the potential for confounding across PFAS as well as other sources of confounding. After considering these factors on the basis of the available data, it was determined that there was minimal concern for substantial confounding, and it was unlikely to fully explain the associations seen in the literature. Although immunotoxicity specific animal studies were not identified, general toxicity or developmental toxicity studies that included immune-related endpoints (i.e., basophil cell counts) were identified. However, these immune-related endpoints in animals were nonspecific and not informative to the immune effects hazard judgment.
  b. For [underlined: thyroid effects], the Toxicological Review concludes the available evidence indicates PFHxS exposure is likely to cause thyroid effects in humans given sufficient exposure conditions, on the basis of a series of short-term studies in rats demonstrating consistent and coherent effects with a clear biological gradient. The thyroid findings for PFHxS were similar for other structurally related long-chain PFAS and determined to be adverse and relevant to humans.
  c. For [underlined: developmental effects], the Toxicological Review concludes the available evidence suggests but is not sufficient to infer whether PFHxS exposure may have the potential to cause developmental effects in humans given sufficient exposure conditions. This judgment is based primarily on the consistent but notably uncertain evidence of decreased birth weight and length from studies of exposed humans in which PFHxS was measured during or shortly after pregnancy. However, the strength of the epidemiology evidence is reduced due to concern for confounding due to sample timing (pregnancy hemodynamics). Evidence in experimental animals from three high confidence studies in rats and mice was indeterminate.
  d. For [underlined: hepatic effects], the Toxicological Review concludes the available evidence suggests but is not sufficient to infer whether PFHxS exposure may have the potential to cause liver effects in humans given sufficient exposure conditions. This conclusion is based on slight evidence of an association between PFHxS exposure and small changes in serum markers of liver disease in humans that was inconsistent across studies, and evidence from experimental animal studies in rats and mice that was also considered slight.
  e. For [underlined: neurodevelopmental effects], the Toxicological Review concludes the available evidence suggests but is not sufficient to infer whether PFHxS exposure may have the potential to cause neurodevelopmental effects in humans given sufficient exposure conditions. This conclusion is based on slight epidemiological evidence of some positive associations between PFHxS exposure and ADHD, or behaviors potentially related to ADHD. Evidence from experimental animal studies was indeterminate.
  f. For [underlined: cardiometabolic effects], the Toxicological Review concludes the available evidence suggests but is not sufficient to infer whether PFHxS exposure may have the potential to cause cardiometabolic effects in humans given sufficient exposure conditions. This conclusion is based primarily on consistent increases in cholesterol in humans. However, limitations in the available epidemiological studies introduced significant uncertainty. Evidence from experimental animal studies was indeterminate.
  g. For [underlined: hematopoietic effects], [underlined: male and female reproductive effects], and [underlined: renal effects] the Toxicological Review concludes there is inadequate evidence to determine whether PFHxS exposure has the potential to cause these effects in humans on the basis of the sparsity of the available evidence.

### G.2.1 External Peer Review Comments on Charge Question 2a (Immune Effects)

#### Peer Review Comment Summary

The majority of the reviewers (8 of 9) agreed with EPA’s conclusions that the available PFHxS exposure is likely to cause immunosuppression in humans given sufficient exposure conditions, primarily on the basis of consistent evidence of reduced antibody responses from epidemiological studies in children and adults. One reviewer disagreed with EPA’s conclusion because they did not believe epidemiology studies should be used as the basis for quantitative dose-response assessment and/or toxicity factor derivation because of issues of confounding. Another reviewer recommended that inflammatory bowel disease could be added to this section. A number of tier 1 and tier 2 comments were provided on EPA’s analyses of the available data. The tiered comments on Charge Question 2a were:

- 10 Tier 1 Recommended Revisions (1 panelist provided 10 comments)
- 4 Tier 2 Suggested Revisions
- 2 Tier 3 Future Considerations

#### Tier 1 Recommended Revisions

[underlined: Tier 1 Recommendation 1 of 10]: One panelist provided 9 of the 10 Tier 1 recommendations on charge question 2a. First, they recommended “Epidemiology studies should not be used as the basis for quantitative dose-response assessment and/or toxicity factor derivation because of issues of confounding.”

[underlined: EPA Response]: This recommendation represents the views of one of the 9 panel members and is not consistent with comments from other peer reviewers on this assessment or peer reviews for other PFAS assessments conducted by EPA. A variety of approaches were used to evaluate the issue of potential confounding by other PFAS (Sections 3.2.2 and 3.2.4, Appendix C.1.1, Appendix D.1.1. See also response to charge question G.1.1, T[underlined: ier 1 Recommendation 3 of 5.]

[underlined: Tier 1 Recommendations 2 and 3 of 10]: The same peer reviewer also provided two recommendations related to statistical significance:

- “For the most part, the presentation of study results appears clear, although the lack of statistical significance should always be explicitly mentioned (as discussed in greater detail later in comments on other sections;” (Comment 2 of 10)
- “EPA’s sentence beginning on line 2 (“Although results were mostly not statistically significant, a general inverse trend was apparent…”) too readily dismisses the role of statistical significance in science and its conclusion should be further caveated by EPA.” (Comment 3 of 10)

[underlined: EPA Response]: Quantitative results are presented with information on the presence or absence of statistical significance (e.g., confidence intervals and indications of p < 0.05 for epidemiology evidence) and, after reconsideration, EPA maintains that the cited sentence provides an accurate description of the pattern of findings across studies. That stated, the limitations of sole reliance on statistical significance for reaching conclusions are well recognized. Additional detail on how statistical significance is considered in IRIS assessments is described in Section 6.1.1 of the IRIS Handbook (U.S. EPA, 2022b). Specifically, as described in the IRIS Handbook, while statistical significance testing is “an important tool for supporting a decision that there is a demonstrable effect”… “consideration of the consistency in patterns of results does not require that all findings are statistically significant.”

[underlined: Tier 1 Recommendations 4, 5, and 6 of 10]: This panelist providing the majority of comments on charge question 2a also provided the following three, related Tier 1 comments:

- “The level of serum antibodies corresponding to a clinically protective level appears to be assay specific, and this should be more clearly presented and described in the draft.” (Comment 4 of 10)
- “adding clarification around assay-specific levels of serum antibodies corresponding to clinically protective levels.” (Comment 5 of 10)
- “For the toxin binding inhibition (ToBI) assay apparently used in these Faroe Islands studies by Grandjean et al., ≥0.01 IU/mL is considered to be the clinically protective level, not the value of ≥0.1 IU/mL indicated by study authors. Considering that 3 of 4 ORs are already not statistically significant for PFHxS in children being associated with antibody concentrations <0.1 IU/mL , the assay-specific protective level of ≥0.01 IU/mL means that the reported decreases in serum antibodies are even less likely to be biologically/clinically significant. This is not surprising given the rarity of tetanus/diphtheria cases, particularly in those fully vaccinated. To say the least, all this brings into serious question the validity of the EPA’s assumptions regarding the clinical relevance/adversity of these serum antibody endpoints, which should be revisited.” (Comment 6 of 10)

[underlined: EPA Response]: The synthesis on vaccine response is primarily based on continuous measures of antibody levels (percent change) which are not subject to a clinically protective cutoff. Dichtomous measures were considered only when the authors presented a cutoff and used it in their analysis: the only instance was in Section 3.2.2 (Timmermann et al., 2021).

In Appendix D.1, EPA explains that:

“A blood concentration for tetanus antibodies of 0.1 IU/mL is sometimes cited in the tetanus literature as a “protective level” and Grandjean et al. (2017) noted that the Danish vaccine producer Statens Serum Institut recommended the 0.1 IU/mL “cut-off” level “to determine whether antibody concentrations could be considered protective”; and Galazka and Kardymowicz (1989) mentions the same concentration), but Galazka et al. (1993) argues: “The amount of circulating antitoxin needed to ensure complete immunity against tetanus is not known for certain. Establishment of a fixed level of tetanus antitoxin does not take into consideration variable conditions of production and adsorption of tetanus toxin in the anaerobic area of a wound or a necrotic umbilical stump. A given serum level could be overwhelmed by a sufficiently large dose of toxin. Therefore, there is no absolute protective level of antitoxin and protection results when there is sufficient toxin-neutralizing antibody in relation to the toxin load (Passen and Andersen, 1986).”

For this reason, EPA did not find that there was a consensus cutoff that could be used. Appendix D.1 further explains that “In the absence of a clear definition of an adverse effect for a continuous endpoint like antibody concentrations, a default BMR of 1 SD change from the control mean may be selected, as suggested in EPA’s draft Benchmark Dose Technical Guidance Document (U.S. EPA, 2012). As noted above, a lower BMR can also be used if it can be justified on a biological and/or statistical basis.”

[underlined: Tier 1 Recommendations 7 and 8 of 10]: In their 7th and 8th comments on charge question 2a, this panelist provided recommendations on two related points:

- “EPA should reconsider their use of the serum antibody endpoints and not use epidemiology studies in this case as a basis for quantitative dose-response assessment and derivation of toxicity factors.” (Comment 7 of 10)
- “EPA should reevaluate the adversity of these presumed antibody level effects, including the association with PFHxS itself, and do so within the context of potential confounding, other limitations, and available human data on disease incidence.” (Comment 8 of 10)

[underlined: EPA Response]: While there is some debate regarding the biological significance of small changes in serum antibody levels (Luster et al., 2005; IPCS, 2012; DeWitt et al., 2016; Agarwal and Cunningham-Rundles, 2007), EPA’s interpretation was supported during the external peer review of the PFOS and PFOA Toxicological Reviews (U.S. EPA, 2022c) as well as by the majority of reviewers of the 2024 IRIS PFDA assessment and this IRIS PFHxS Toxicological Review. Vaccine immune serum titers are functional measures of adaptive immune response and important indicators of clinically relevant immunotoxicity. Reduced antibody production is an indication of immunosuppression and may result in increased susceptibility to infectious diseases generally (i.e., not limited to those specifically studied). This falls under EPAs definition of an “adverse effect” as a “biochemical change, functional impairment, or pathologic lesion that affects the performance of the whole organism or reduces an organism’s ability to respond to an additional environmental challenge” (U.S. EPA, 2002). Reduced antibody production is thus an appropriate effect for the derivation of a candidate RfD. Further, the approach taken in the PFHxS assessment is supported by a consensus panel during external peer review of the PFOA and PFOA assessments (U.S. EPA, 2022c) and the PFDA assessment as well as the other reviewers of this assessment. Support for use of epidemiological data is discussed in EPA’s response to Charge 1a. (Appendix G.1.1), T[underlined: ier 1 Recommendation 3 of 5]

[underlined: Tier 1 Recommendation 9 of 10 (indicated as “conditional”)]: Lastly, the same panelist recommended “Alternatively, the assessment should specifically outline why ATSDR, a federal public health agency of the U.S. Department of Health and Human Service (HSS)/Centers for Disease Control and Prevention (CDC) charged with protecting communities from the harmful health effects related to exposure to hazardous substances, is wrong about the epidemiology literature being inadequate for use as the basis for toxicity factors.”

[underlined: EPA Response]: IRIS assessments are independent analyses of the available evidence that can arrive at different conclusions than those drawn by others and discussing and comparing decisions across different agencies with different decision contexts, mandates, and guidelines is outside the scope of an IRIS assessment.

[underlined: Tier 1 Recommendation 10 of 10:] A separate panelist reiterated their request for EPA to incorporate two studies (Narizzano et al. 2023 and Weatherly et al. 2024).

[underlined: EPA Response]: These studies are summarized in Table B-5 in Appendix B but not incorporated into the synthesis text (see EPA response to Tier 1 Recommendation 1 of 13 under charge question 1c). Briefly, one the two studies one, (Weatherly et al., 2024) was tagged as supplemental (non-PECO route of exposure) and the other (Narizzano et al., 2023) was not integrated into the main assessment because it was not considered impactful to hazard or toxicity value conclusions.

#### Tier 2 Suggested Revisions

[underlined: Tier 2 Suggested Revision 1 of 4]: “Add inflammatory bowel disease including Ulcerative colitis and Crohn’s disease.”

[underlined: EPA Response]: EPA reviewed the literature for ulcerative colitis and Crohn’s disease. While this is an important developing area of research, since most of the available studies do not report a positive association with PFHxS exposure, EPA did not add these outcomes as doing so would not influence assessment conclusions.

[underlined: Tier 2 Suggested Revision 2 of 4]: requested to “address the fact that two Stein, 2016 studies are evaluated in Figure 3-13 however no designation for a or b publication is given. Please clarify for this table as the text independently reviewed both Stein, 2016a and b.”

[underlined: EPA Response]: Figure 3-13 has been updated to include a and b designations.

[underlined: Tier 2 Suggested Revision 3 of 4]: “[EPA… should consider including ensuring balance as to the assessment’s presentation of relevant evidence as an additional criterion for new study inclusion.”

[underlined: EPA Response]: The potential for new studies to change the balance of evidence was a factor that was considered in determining whether they would be influential on assessment conclusions (and thus incorporated into the evidence synthesis). Table B-5 in Appendix B of the supplemental materials lists newly identified studies, the health outcome that these inform, a brief results summary, and EPA’s disposition on incorporation and characterization of impact.

[underlined: Tier 2 Suggested Revision 4 of 4]: “Although noted below for thyroid effects, a broader recommendation is to provide introductory comments that consider the state of knowledge regarding other forms of PFAS, particularly PFOA and PFOS. The issue is to recognize that well-established effects of these forms of PFAS make it more likely that PFHxS would have comparable effects and may help to pinpoints specific processes or endpoints to focus on in the review. But likewise, these associations for other forms of PFAS pose the challenge of confounding and isolating the specific impact of PFHxS. For each of the health endpoints, a brief summary of the established effects of other forms of PFAS would help to provide context for interpreting the evidence on PFHxS. It could be drawn from previous EPA documents and summarized in only a sentence or two. Clarification provided: For consistency, EPA could cite its own reviews of these other forms of PFAS with regard to identified associations. Alternatively, other authoritative reports such as those by ATSDR on PFAS toxicity could be used. It could be as brief as a table of chemicals and outcomes with some indication where the clearest associations have been found.

[underlined: EPA Response]: The intent of this assessment is to develop toxicity values for PFHxS based on the available chemical-specific evidence. A clear grouping strategy does not yet exist and is hindered by a lack of data. To start to address the need, EPA has developed a chemical category approach with the goal for application to PFAS so that these will be able to be readily characterized by a chemical structure (Patlewicz et al., 2022). In addition, EPA has developed systematic evidence maps (SEM) to collect and inventory the current data on thousands of PFAS (Radke et al., 2022;Carlson et al., 2022). The SEM inventory the available toxicity data across broader classes of PFAS in parallel with tiered toxicity testing. The SEM highlight data gaps and fit-for -purpose assessment opportunities for emerging PFAS of concern (Radke et al., 2022; Carlson et al., 2022). EPA has also partnered with the National Institute of Health (NIH) to develop tiered toxicity testing strategies to fill data gaps and inform decisions on grouping and prioritization (https://www.epa.gov/sites/default/files/2019-02/documents/pfas action plan 021319 508compliant 1.pdf (https://www.epa.gov/sites/default/files/2019-02/documents/pfas_action_plan_021319_508compliant_1.pdf)) These ongoing parallel efforts within EPA are separate from the IRIS PFAS assessments, and all are interlinked components of EPA’s PFAS Strategic Roadmap (PFAS Strategic Roadmap: EPA’s Commitments to Action 2021-2024 | US EPA (https://www.epa.gov/pfas/pfas-strategic-roadmap-epas-commitments-action-2021-2024)). The IRIS Toxicological Review of PFHxS does include a summary of hazard conclusions across published EPA PFAS human health assessments (Section 4.1 Table 4-1).

Increasing the use of conclusions on surrogate PFAS with rich evidence bases (e.g., PFOA and PFOS) to inform other PFAS with less robust evidence bases is work that EPA is currently investigating as part of the EPAs PFAS Strategic Roadmap to advance the understanding around PFAS chemicals.

#### Tier 3 Future Considerations

[underlined: Tier 3 Future Consideration 1 of 2]: Future animal studies should investigate relevant immune endpoints for PFHxS alone and as commonly observed mixtures.

[underlined: EPA Response]: EPA appreciates this future consideration for PFAS research.

[underlined: Tier 3 Future Consideration 2 of 2]: a panelist commented: “There is also some experimental literature on this topic (PFHxS immune effects). The question is whether these contributions to the topic should be included?”

[underlined: EPA Response]: EPA evaluated the results from Narizarro et al., 2023 and determined that the results do not influence draft judgments or provide key insights into key science issues, nor do they provide additional insights into potential mechanisms of PFHxS-induced effects and therefore this study was not integrated into the draft. Weatherly et al., 2024 was also evaluated and EPA determined that the study did not meet PECO criteria as outlined in the protocol document (U.S. EPA, 2019b). Further the results presented in this study do not influence draft judgments or provide key insights into key science issues, nor do they provide additional insights into potential mechanisms of PFHxS-induced effects. However, both studies were added to Table B-5 in Appendix B. EPA appreciated this future consideration for PFAS research.

### G.2.2 Public Comments on Noncancer Hazard Identification: Immune Effects

Public Comment (AWWA): “Epidemiological studies of vaccine response in relation to a chemical may be useful for screening for evidence of immunomodulation; however, the existing data on vaccine response are not adequate in and of itself to conclude that PFHxS exposure is likely to cause immunosuppression. Additional data to support immunosuppression are needed from animal toxicity studies, in vitro studies with human cells/tissues spanning concentrations relevant to human exposures, or well-conducted epidemiological studies that show reduced host resistance to infection consistent with immunosuppression. A recent meta-analysis (Crawford et al. 2023) reported small decreases in vaccine response per doubling of PFHxS (results from studies were re-expressed based on log2-PFAS): the summary associations for tetanus in children were β −0.07 (95% CI: −0.16 to 0.03), which is an approximate 7% decrease in antibodies against tetanus per doubling of PFHxS serum concentration. The summary estimate was based on 4 cohorts: Faroe Island Cohort 3 (Mogensen et al. 2015; Grandjean et al. 2012, 2017a, 2017b), Faroe Islands Cohort 5 (Grandjean et al. 2017b), Norwegian Mother and Child Cohort Study (Granum et al. 2013), and a cross-sectional analysis of Greenland children, 7 to 12 years old (Timmermann et al. 2022). However, the clinical and biological significance of such small differences is unclear. There are numerous factors that affect humoral immunity and vaccine response, and many were not measured in the available epidemiological studies. The Faroese diet is a common source of polychlorinated biphenyls (PCBs), methyl mercury (MeHg), and certain PFAS, especially PFOS (Weihe et al. 2008). PCBs and MeHg each have been implicated in studies of humoral immunity. Weihe et al. (2008) reported that PFAS exposure from eating whale meat is significant: “On a relative scale, a high intake of two pilot whale dinners per month is associated with increases in the 14-year serum concentrations of PFOS, PFNA, and PFDeA by almost 25%, 50%, and 100%, when compared to concentrations in subjects eating little or no whale at all (Table 3). Fish dinners had a much weaker effect, although each weekly fish dinner augmented the PFHxS concentration by about 10%..” Therefore, it may be difficult to disentangle which coexposures confound or mediate the association between specific PFAS and decreased vaccine response. Budtz-Jorgensen and Grandjean (2018) cited Grandjean et al. (2012) when they reported that confounding by MeHg and PCBs was unlikely because of their weak correlations with serum concentrations of PFAS. However, the authors reported pairwise Pearson’s correlations between serum PCBs and the different PFAS, which varied from 0.00 (PCBs and PFOA) to 0.29 (PCBs and PFNA) measured at age 5 years. The weak correlations reported between PCBs and PFAS might reflect the small variability in the PCBs and/or PFAS concentrations and/or a non-linear relationship between PCBs and PFAS. The small variability in the PCB concentrations is indicated by the geometric mean (GM) and interquartile range (IQR) of the sum of the PCB concentrations in maternal serum (GM 1.25 ug/g lipids, IQR 0.83–1.90 ug/g lipids) and of the sum of the PCB concentrations at the 5-year pre-booster exam (GM 1.14 ug/g lipids, IQR 0.0–1.93 ug/g lipids). This suggests that a more robust assessment of confounding by PCBs and MeHg is needed. Grandjean et al. (2012) did not discuss correlations between MeHg and PFAS in these analyses and it is not clear if confounding by MeHg has been evaluated. Overall, it seems likely that the PCBs, methyl mercury, and PFOS (in particular) are correlated due to a common source (Faroese diet) for these chemicals. In addition, many unmeasured factors (e.g., stress, micronutrients such as vitamin D, maternal antibodies) play a role in response to vaccination (Sadarangani et al. 2015). The Faroe Islands population may have a higher percentage of the population with vitamin D deficiency because it is geographically located at northern latitudes (Dalgård et al. 2010); whether vitamin D is related to PFAS concentrations has not been evaluated. Vitamin D plays a role in maintaining the body’s immune homeostasis. Whether vitamin D influences PFAS levels or PFAS levels influence vitamin D levels (and its metabolites, and calcium uptake, serum calcium concentrations, and subsequent physiological processes) has not been explored in research studies to date. Although Grandjean et al. (2012) adjusted for certain potential confounders (age, sex, booster type), the analyses of IgG concentrations at age 7 years in relation to PFAS exposure at age 5 years or in relation to maternal PFAS exposure did not account for time since last vaccination. This may be important because it is unclear whether all participants who had antibodies measured at age 7 years received a booster shot at their 5 year exam, based on information presented in the text and Tables 2 and 3 of Grandjean et al. (2012). Grandjean et al. (2012) reported that 587 subjects participated in one or more of examinations that took place at 5 years (pre-booster), 4 weeks after 5 yr exam (postbooster) and 7 years. It seems a safe assumption that any participant who attended the age 5 post-booster exam (n=440) had a booster shot at age 5; however, it is not clear if all age 5 participants at pre-booster medical exams (n=532, Table 2; n=537, Table 3) received a booster shot. A participant may have had blood drawn at the age 5 exam and opt out of a booster shot, although these numbers are expected to be small. Similarly, based on the inclusion criteria (showed up at one or more of three exams), a participant may have attended the age 7 exam (and had blood drawn to determine antibody concentrations) but not have attended the age 5 year exam (and not have had a booster shot). Under this scenario (no booster at age 5), the antibody concentrations at age 7 are likely to be very low. Time since vaccination was only adjusted for in the analysis of age 5 post-booster antibodies; it was not accounted for in the analysis of age 5 exam (prebooster) antibodies or age 7 antibodies. The transfer of maternal antibodies was not considered (it is unknown how many pregnant women were vaccinated during pregnancy) and maternal antibodies can interfere with the vaccination response in infants (Albrecht and Arck 2020). Higher antibodies from the mother may inhibit the response to tetanus and diphtheria toxoids. The timing of vaccination matters in part because maternal antibodies wane after a few months. It takes 3 doses before an infant will produce sufficient antibodies for protection against tetanus and diphtheria although these wane over time, hence the need for booster vaccinations. It is also unknown how many infants were breastfed and the duration of breastfeeding. The duration of breastfeeding will affect both transfer of antibodies and PFAS exposure in infants. Figure 2 below (copied from WHO 2018) shows the kinetics and the durability of response to tetanus. A single dose primes the immune system but is not protective; after a second dose, the mean level of antibodies against tetanus exceeds 0.01 IU/mL (described in WHO (2018) as a “minimum putatively protective level.”) Mean antibody levels generally decline one year after the second dose. After a third (primary) dose, immunity is boosted, persists above the protective threshold for a time, and then wanes by around age 5 years. This means that at age 5 years, there is smaller variability in antibodies against tetanus between individuals than there is in later years after individuals have attained prolonged immunity from additional booster shots. Nevertheless, there can be a number of children at age 5 and at age 7 that fall below a value of 0.1 IU/mL (which was the level of protection relied upon by Grandjean et al. 2012 to indicate seroprotection). Additional booster doses increase the antibody levels and the duration of immunity. It generally takes at least five doses to increase the duration of immunity for at least 20 years. The United Nations Environment Programme (UNEP 1996) of the World Health Organization described assays recommended by the National Research Council (NRC 1992) for preliminary assessment of individuals exposed to immunotoxicants, including secondary antibody responses to proteins (e.g., diphtheria, tetanus, poliomyelitis) and polysaccharides (e.g., pneumococcal, meningococcal). Specifically, the UNEP (1996) described the tests for antibody response to immunization: “In order to test for T cell-dependent antibody responses, commercially available diphtheria-tetanus vaccine can be given in recommended doses. Blood is taken two weeks after each injection and tetanus and diphtheria antibodies are determined. In patients who have been immunized with diphtheria-tetanus or diphtheria-pertussis-tetanus vaccine, one booster injection is given before determination of antibodies. In testing for T cell-independent antibody responses, commercially available pneumococcal vaccine can be given in recommended doses. Three doses of killed poliomyelitis vaccine (10 mL intramuscularly, at intervals of two weeks) can also be used as the immunogen. Blood is taken two weeks after the last injection, and antibody is usually determined by virus neutralization. [UNEP 1996, pp. 238–239]”

Therefore, it seems that the most relevant findings on diphtheria and tetanus antibody response from the studies in the Faroe Islands is the 5 year post-booster responses compared to PFAS serum measured at age 5 years pre-booster, four weeks earlier. None of the studies of the Faroe Islands reported whether any person had a post-booster concentration that fell below 0.1 IU/mL four weeks after receiving a booster. In contrast, the vaccine response measured at age 7 is expected to have a larger variability between individuals than the response measured at age 5. (Note: In a separate analysis of antibody response at age 7 that is adjusted for the study participants antibody concentrations at age 5, the effect of PFHxS (as well as other PFAS) is attenuated.

However, this analysis may incompletely adjust for the effect. A statistical analysis that accounts for repeated measures (rather than adjusting for the age 5 antibody concentrations as an independent variable in a linear regression) is needed.

Finally, there are primarily null associations between PFHxS and infectious diseases in the epidemiological literature (Dalsager et al. 2021; Goudarzi et al. 2017; Impinen et al. 2018; Wang et al. 2022; Manzano-Salgado et al. 2019; Kvalem et al. 2020; Dahlsager et al. 2016; Grandjean et al. 2020); therefore, there is little support of adverse immune effects in humans from PFHxS exposure.”

[underlined: EPA Response]:

- Adversity of antibody changes - There has been ongoing debate about the biological significance of small changes in antibody levels following vaccination, but EPA’s interpretation that the changes are adverse was supported by a consensus panel during external peer review of the PFOS and PFOA assessments (EPA 2022), as well as by the large majority (8 of 9) of the current expert peer review panel. Immunomodulatory effects observed in children may be broadly indicative of developmental immunosuppression impacting these children’s ability to protect against a range of immune hazards, and as such meet EPA’s definitions for adversity.
- Confounding - With regard to confounding by co-exposures such as PCBs, this was considered as part of the study evaluation process and specifically discussed and considered by the PFHxS external peer review panel. The studies in the Faroe Islands considered the potential for confounding by PCBs. They reported that there were only weak correlations between PFAS and PCB exposure, and that associations did not materially change with adjustment for PCBs. Thus, confounding by PCB exposure was not considered likely to significantly bias the effect estimates. For any of the other factors listed in the comment (stress, micronutrients, etc.) to confound the association, they would need to be associated with both immune suppression and PFHxS exposure, and there are no data to suggest that this is the case. Similarly, time since last vaccination is not plausibly associated with PFHxS exposure, so this cannot act as a confounder.
- Maternal antibodies - the studies measured the total antibody levels rather than specifically in response to vaccination; interference by higher antibodies from the mother would not result in lower overall antibody levels.
- Kinetics and durability of response - An analysis that accounts for repeated measures would be valuable, but the lack of it does not negate the available data.
- Infectious disease - As stated in the assessment, infectious disease is a more difficult outcome to measure and thus is subject to greater nondifferential outcome misclassification which is expected to bias the results towards the null. Thus, the lack of positive findings in the evidence base does not reduce confidence in the antibody response data.

Public Comment [underlined: (AWWA)]: “The only statistically significant effect of PFHxS on immune function cited in the Toxicological Review is a decrease in eosinophils in male, but not female, Sprague Dawley (SD) rats (NTP 2018), which was not considered adverse by USEPA. In fact, the NTP (2022) “Technical Report on the Toxicity Studies of Perfluoroalkyl Sulfonates,” which provided NTP’s conclusions regarding the PFHxS study cited by USEPA (NTP 2018), did not report any evidence of immune dysfunction associated with PFHxS exposure, despite the fact that sustained plasma concentrations as high as 100,000 to 200,000 ng/mL were achieved, in contrast to epidemiological associations reported at human plasma concentrations on the order of 0.6 ng/L (Grandjean et al. 2012), calling into question the relevance of the observed epidemiological associations to any actual human health impacts. In vitro studies with human cells/tissues over a range of relevant concentrations, similar in design to the Kasten-Jolly and Lawrence (2022) study of PFOA and PFOS, are critically needed to elucidate a plausible MOA for PFHxS effects at the plasma concentrations reported in epidemiological studies in order to support an assessment of causality.”

[underlined: EPA Response]: It is certainly true that observing an immune effect in animal or in vitro studies would increase our certainty in the association observed in epidemiology studies, but the lack of availability of these studies does not detract from the epidemiology evidence. Please also see EPA responses related to statistical significance in response to one of the peer reviewers above (Tier 1 Recommendations 2 and 3 of 10).

### G.2.3 External Peer Review Comments on Charge Question 2b (Thyroid Effects)

#### Peer Review Comment Summary

Four reviewers commented that they agreed with EPA’s conclusions. One reviewer suggested considering additional human studies and meta-analyses and further discussing the impact of modification of clinical lab measures by PFAS and protein binding of carrier proteins that affect thyroid metabolism in humans. This reviewer also suggested revising the text about biomarkers in humans. Another reviewer commented that reporting of results, particularly where the confidence interval includes 1, needs to be appropriately caveated in this section. A separate reviewer commented that consideration of a central hypothyroid effect would provide other mechanisms of the reported thyroid function changes and potentially help explain why changes in T3, T4, and TSH are not entirely consistent with conventional hypothyroid or hyperthyroid effect. This reviewer also commented that the designation of studies that did not report or consider time of day for serum thyroid test measurement as deficient may be too strict, as it is generally accepted that any small diurnal variation in these tests is negligible and clinically insignificant. A reviewer suggested naming the PFAS which were structurally similar and had a reasonably clear relationship with thyroid function to increase the strength of this section. Lastly, a reviewer recommended noting that the effect of test timing on serum thyroid tests is small compared to the relative inter-individual variation within a normal population and suggested elaborating on what “imprecise” means when used to refer to T4 estimates. The tiered comments on Charge Question 2b were:

- 1 Tier 1 Recommended Revisions
- 12 Tier 2 Suggested Revisions from five panelists (two panelist had four suggested revisions each)
- 2 Tier 3 Future Considerations from one panelist

#### Tier 1 Recommended Revisions

[underlined: Tier 1 Recommended 1 of 1]: panel member commented that “reporting of results, particularly where the confidence interval includes 1, needs to be appropriately caveated in this section.”

[underlined: EPA Response]: Consistent with the EPA IRIS PFAS protocol and the IRIS Handbook, statistical significance of epidemiological data (which can inform random error considerations and help some decision-making) was not the primary determinant of what is being highlighted, especially during evidence synthesis for hazard identification. As with all observational epidemiological data, the role of chance/random error was considered in addition to the more important alternative explanations such as systematic errors. As noted in the US EPA Handbook “However, consideration of the consistency in patterns of results does not require that all findings are statistically significant…A presence of a change that lacks statistical significance can be used to support conclusions of consistency. Nor should all statistically significant results be interpreted as evidence of an effect..” More details on this topic are included in the EPA IRIS PFAS Systematic Review Protocol. For transparency and to address the role of random error (i.e., chance), the assessment consistently displays effect estimates along with confidence intervals (as the preferred and more informative measure of precision vs. an arbitrary choice of an alpha level denoting statistical significance) and generally highlights the extent of individual study results that were statistically significant and non-significant.

#### Tier 2 Suggested Revisions

[underlined: Panel Member Tier 2 Suggested revisions on related points]:

- EPA could clarify that thyroid binding protein dynamics are clearly altered by PFAS exposure including PFOS- and PFHxS exposure. There is little doubt of this. The clinical significance of this binding is what is harder to clarify.” (Comment (1 of 12 )
- “recommended further discussing the impact of modification of clinical lab measures by PFAS and protein binding of carrier proteins that affect thyroid metabolism in humans.” (Comment (4 of 12 )
- “The assessment of inconsistency for thyroid outcomes is fair for codeable diagnoses, but incomplete as regards science and misleading as regards biomarkers. Already discussed by EPA, PFHxS will consistently bind to carrier proteins which are relevant to thyroid hormone transport such as transthyretin (see page 49/459) and which can affect lab measures including of thyroid hormones. (These are clinical lab measures, so they do get ordered by doctors. PFAS reliably modifies the protein binding measures). The thyroid section of the document mentions this in relationship to rodents only (see p. 104/459). I think the basic conclusion about inconsistency is supportable, but the protein binding of PFHxS and other PFAS to carrier proteins (transthyretin and others!) that affect thyroid metabolism (and could be another source of attenuation bias) is undoubted in both humans and rodents. This consistency should be mentioned under thyroid effects in humans.). This section of the document contains many reasonable considerations. One that seems reasonable on the surface is questionable upon scrutiny.” (Comment 5 of 12)

[underlined: EPA Response]: As noted in the document Section 3.2.1, mechanistic studies exploring the effects of PFHxS on thyroid hormone transport have shown that PFHxS competes with T4 for binding to TTR, but not thyroxine-binding globulin (TBG) (Weiss et al., 2009; Ren et al., 2015; Ren et al., 2016; Huang et al., 2023). While it is possible and reasonable to hypothesize that PFHxS is competitively binding to human TTR, there are no data from human epidemiological studies in the current evidence base to confirm this assumption. However, TTR binds only a small portion of the circulating thyroid hormones (15%–20%) (Refetoff, 2015), and confirmatory studies in model systems known to be relevant to humans would be needed to have reasonable certainty in understanding the potential role of PFHxS-induced alterations to thyroid hormone-responsive genes in humans.

[underlined: Tier 2 Recommended revisions 2 of 12]: Human studies omitted. P. 85/459 – 88/459 (table) Suggested revisions. It is unclear why the study of Total triiodothyronine (T3) from the heavily exposed Ronneby population (Silva et al., 2020) is omitted. Is it because addresses a mixture effect of PFOS and PFHxS on T3? The study modeled a “critical effect” of >10% decrease in T3 in about 2.3% of the population, with the more prominent effect among women. Because this finding is not apparently consistent with the Aimuzi and Crawford studies cited, it is worth considering.

[underlined: EPA Response]: This study was tagged as supplemental because an effect estimate specific to PFHxS was not available (the study categorizes participants based on likely total PFAS exposure. While PFHxS is one of the primary PFAS in that population, PFOS exposure is higher and thus it is not possible to determine whether effects were due to PFHxS or PFOS. Given the overall inconsistency of the evidence, it is not expected to have an influence on the synthesis conclusion regardless.

[underlined: Tier 2 Recommended revisions 3 of 12]: panel member suggested: “Meta-analyses can be helpful. Include them where possible. A useful meta-analysis concerning Total T4 is Kim, MJ et al., 2018 based on 11 studies. It found a (z value, −0.04; 95% CI: −0.07, −0.01) in adults for PFHxS and Total T4 without associations in pregnancy.”

[underlined: EPA Response]: EPA does not typically use external systematic reviews/meta-analyses as primary support without independent review and validation. EPA does cross-check references listed in the meta-analyses to ensure the comprehensiveness of our literature searches. In this case specifically, a number of studies identified by EPA were published after the meta-analysis cut-off date, which would be likely to substantially change the estimate.

[underlined: Tier 2 Recommended revisions 4 of 12]: A panel member “recommended further discussing the impact of modification of clinical lab measures by PFAS and protein binding of carrier proteins that affect thyroid metabolism in humans.”

[underlined: EPA Response]: The revised assessment includes text in Section 3.2.1 that discusses studies in the evidence base that have reported on the effects of PFHxS on thyroid hormone transport proteins in experimental animals. The relationship of this binding to human thyroid metabolism or human health outcomes is not known, as noted in prior EPA responses.

[underlined: Tier 2 Recommended revisions 6 of 12]: a panel member commented “public comments appear to contain relevant information that should be duly considered to strengthen the analyses and/or scientific basis for the assessment conclusions.”

[underlined: EPA Response]: EPA has taken comments received from the public into consideration and provides responses to each comment in this Appendix.

[underlined: Tier 2 Recommended revisions 7 of 12]: a panel member commented “The summary of animal and human studies on PFHxS exposure and adverse thyroid effects is well-organized and clearly described. It should be noted that the “Thyroid effects summary” at the end of the human studies section, “Mechanistic evidence and supplemental information,” and “Evidence integration” text summarizing the observation of generally lower serum peripheral thyroid hormone levels (T3 and T4) in the absence of TSH change/elevation is mostly based on the assumption that the hypothalamic-pituitary-thyroid (HPT) axis remains intact with PFHxS exposure. Although the scientific justification for the studies’ confidence conclusions is reasonable and is appropriately supported by the summarized data, consideration of a central hypothyroid effect in these areas of the text would provide other possible mechanisms of the reported thyroid function changes, while potentially help explain why the changes in T3, T4, and TSH are not entirely consistent with the expected physiology of a conventional hypothyroid or hyperthyroid effect.”

[underlined: EPA Response]: Text discussing central hypothyroid effect as a potential PFHxS-induced effect was added to the evidence integration subsection of Section 3.2.1 of the revised Toxicological Review.

[underlined: The following Tier 2 recommendations were combined due to their similarity]:

- “the designation of studies that did not report or consider time of day for serum thyroid test measurement as deficient may be too strict, as it is generally accepted that any small diurnal variation in these tests is negligible and clinically insignificant.” (Comment 8 of 12)
- Panel member recommended noting that the effect of test timing on serum thyroid tests is small compared to the relative inter-individual variation within a normal population (Comment 11 of 12)

[underlined: EPA Response]: The text in the Toxicological Review has been revised to emphasize that lack of consideration of fasting or diurnal variation was not considered a major source of bias and that studies were not downgraded in overall study confidence if this was the primary limitation identified (i.e., such a limitation led to a rating of “deficient” only within the outcome domain). This limitation alone did not decrease the potential influence of these studies on the evidence synthesis judgment as such studies were medium confidence overall. The revised text also describes the value in identifying this type of potential bias towards the null when interpreting inconsistent results such as those included in this section.

[underlined: Tier 2 Recommended revisions 9 of 12]: Panel member commented “Page 3-57 (lines 7–9): Suggest clarifying the subclinical hypo- and hyperthyroidism are defined as isolated abnormal TSH levels (i.e., in the setting of normal T3 and T4 levels and only if the HPT axis is intact).”

[underlined: EPA Response]: Suggested revision added to revised Toxicological Review.

[underlined: Tier 2 Recommended revisions 10 of 12]: Panel member commented “suggested naming the PFAS which were structurally similar and had a reasonably clear relationship with thyroid function to increase the strength of this section.”

[underlined: EPA Response]: The names of the long and short chained PFAS have been added to the existing text on this issue (described only by chain length in the external draft) as follows: “a pattern of decreased T4 without pronounced (or detectable) changes in TSH is consistent with hypothyroxinemia and has been observed in some analyses of other PFAS, including several long-chain (e.g., PFOA and PFOS) (Kim et al., 2018a) and short-chain (e.g., PFBS, PFBA, and PFHxA) (U.S. EPA, 2021a, b, 2022a).”

[underlined: Tier 2 Recommended revisions 11 of 12]: Panel member recommended noting that the effect of test timing on serum thyroid tests is small compared to the relative inter-individual variation within a normal population

[underlined: EPA Response]: The text in the Toxicological Review has been revised to emphasize that lack of consideration of fasting or diurnal variation was not considered a major source of bias and that studies were not downgraded in overall study confidence if this was the primary limitation identified (i.e., such a limitation led to a rating of “deficient” only within the outcome domain). This limitation alone did not decrease the potential influence of these studies on the evidence synthesis judgment as such studies were medium confidence overall. The revised text also describes the value in identifying this type of potential bias towards the null when interpreting inconsistent results such as those included in this section.

[underlined: Tier 2 Recommended revisions 12 of 12]: Panel member suggested elaborating on what “imprecise” means when used to refer to T4 estimates.

[underlined: EPA Response]: The text was revised to clarify that this was used to indicate wide confidence intervals around an effect estimate.

#### Tier 3 Future Considerations

[underlined: Tier 3 Future considerations 1 of 2]: Panel member commented: “Since the human studies on thyroid effects of exposure to PFHxS have mixed findings, it is recommended to conduct a meta-analysis and systemic review to determine the extent and strength of this potential association in humans.”

[underlined: EPA Response]: Based on the individual study results, EPA interprets that a meta-analysis would not change the evidence synthesis conclusion but agrees it could be an interesting future research project given the volume of literature on the topic.

[underlined: Tier 3 Future considerations 2 of 2]: Panel member commented: “Since many animal studies have shown consistent effects of PFHxS on the thyroid system in animals, but the findings in human studies are mixed, it is recommended to develop a biologically based dose-response (BBDR) model to describe the impact of PFHxS on the hypothalamic-pituitary-thyroid (HPT) axis (McLanahan et al. 2008; Lumen et al. 2013; Fisher et al. 2023). One strength of BBDR models is that they are physiologically-based, so that they can be extrapolated from animals to humans. These models will improve our understanding of the effect of PFHxS on the thyroid system in both animals and humans.”

[underlined: EPA Response]: EPA will consider this comment as the agency continue to identify opportunities to advance dose-response methods for animal toxicology and human epidemiologic studies. The development of toxicodynamic or biologically-based dose-response models is an intensive effort and these models require sufficient data to ascertain the mode-of-action and to support model parameters associated with its key events. Currently, EPA does not consider the MOA and ADME data for PFHxS to be sufficient to develop a biologically-based dose-response model. But, as these data continue to be collected, development of such a model may be possible in the future.

### G.2.4 Public Comments on Noncancer Hazard Identification: Thyroid Effects

Public Comment [underlined: (AWWA)]: “The animal studies cited in the Toxicological Review suggest that PFHxS dosing at 1 mg/kg/d and above is associated with decreases in T4 and T3, but not TSH. However, the rodent and human differ significantly in the processes associated with thyroid hormone storage, plasma binding and clearance (USEPA 2002). The potential impact of these differences is evidenced by the fact that similar thyroid effects have been reported for PFOS in the rodent (Thibodeaux et al. 2003), but no effects were seen in monkeys dosed with PFOS at 11–17 mg/kg/d (Chang et al. 2017).”

[underlined: EPA Response]: While PFOS was not found to have thyroid effects in the non-human primates in the Chang 2017 study, multiple epidemiological studies on PFOS reported effects on the thyroid. The PFHxS evidence base does not contain any studies of any duration length in non-human primates. As supported by the peer review (see above), EPA has concluded that the available evidence for PFHxS indicates that PFHxS exposure likely causes thyroid effects in humans given sufficient exposure conditions.

### G.2.5 External Peer Review Comments on Charge Question 2c (Developmental Effects)

#### Peer Review Comment Summary

The majority of the reviewers (6 of 9) commented that they agreed with EPA’s conclusions. One reviewer recommended revising EPA’s weight of evidence for birth weight reductions to “moderate” evidence. One reviewer expressed reservations about downgrading studies that did not consider eGFR during pregnancy and increasing clarity about when eGFR adjustment is desirable and undesirable. The reviewer also commented that multiple additional studies should be included in the developmental section. Another reviewer suggested reviewing the decision not to discuss “medium” confidence animal studies in Table 3-21 and adding an explanation. Further, the reviewer noted that there are two publications from 2022 from cohorts in Quangxi, China and Maoming, China, that should be considered; these publications are identified by another reviewer as well. Another reviewer commented that in the absence of statistical significance, EPA should make it clear that they cannot say with confidence that chance cannot explain the findings. Lastly, one reviewer declined to comment on charge question 2c, noting that the topic is outside of his area of expertise. The tiered comments on Charge Question 2c were:

- 9 Tier 1 Recommended Revisions from four panelists (one panelist had four comments)
- 7 Tier 2 Suggested Revisions from one reviewer
- 1 Tier 3 Future Considerations from one reviewer

#### Tier 1 Recommended Revisions

[underlined: Tier 1 Recommended Revision 1 of 9]: A panel member “recommended revising EPA’s weight of evidence for birth weight reductions to “moderate” evidence.”

[underlined: EPA Response]: It is noted that this represents the opinion of only one panel member among the 8 experts who provided comments. The EPA spent considerable time evaluating different alternative explanations for individual study results then collectively across each evidence stream focusing a lot on consistency and determinants of consistency and/or other patterns of the data including study magnitude and precision of reported effect estimates. Given the inconsistent results and source of uncertainty detailed in the main text and appendices, EPA retains the “slight” judgment for developmental epidemiological effects in the revised assessment.

[underlined: Tier 1 Recommended Revision 2 of 9]: panel member commented “Increasing clarity about when eGFR adjustment is desirable and undesirable.”

[underlined: EPA Response]: The potential impact of eGFR and other measures of pregnancy hemodynamics remains an open question. EPA is not aware of any direct evidence in the available literature indicating that adjustment for these parameters was impactful in developmental epidemiological studies of PFAS (as noted in reply above). EPA has documented this and provides some additional text on this challenging topic in Appendix Section C.1.4 of the revised assessment entitled Pregnancy Hemodynamics Background. Generally speaking, EPA prefers studies with earlier biomarker sample timing and when the collection sample timing does not vary dramatically across individuals within the same study to reduce the potential impact of hemodynamics. The potential value of statistical adjustment for these parameters is unknown but may be clarified in the literature in the future.

[underlined: Tier 1 Recommended Revision 3 of 9]: A panel member recommended “[EPA] review and determine why the “medium” confidence animal studies were not discussed in Table 3-21, and requests action to modify or add explanation. (Note this is directly relevant to the questions posed by the USEPA to the reviewers in point 2c. which refers to both the high and medium confidence studies.)”

[underlined: EPA Response]: This was an error. The table has been updated to include the 3 medium confidence animal studies available for this hazard in Section 3.2.3 of the revised Toxicological Review.

[underlined: Tier 1 Recommended Revision 4 of 9]: A panel member commented “an unresolved Tier 1 necessary revision for this section is how to handle the emerging recent publications from the Chinese cohorts (See additional publications discussed by Dr. Ducatman in his developmental endpoints critic). These publications do not appear to be on the most updated of the EPA characterization of studies identified after public release of the draft “IRIS Toxicological Review of Perfluorohexanesulfonic Acid.” USEPA should review these new publications and indicate how these publications, which may have missed the deadline for incorporation, are handled. It is the opinion of this reviewer that missing such significant new studies would be essential to consider. At a minimum USEPA should as a part of this revision include an addendum citing this newly evolving information.”

[underlined: EPA Response]: Appendix B, Table B-5 acknowledges the recent studies from China noted by the panelist (Yu et al., 2022; Siwakoti et al., 2023; Qin et al., 2023a; Liao et al., 2022b). Like other newly identified literature, the studies were considered in the context of their ability to impact hazard conclusions and toxicity values, and none were interpreted by EPA as likely to impact hazard or toxicity values. It is noted that there is a wealth of developmental effects data synthesized in the assessment to inform EPA’s conclusions.

Further, EPA’s recently published meta-analysis (by Ru et al., 2024, doi: 10.1136/oemed-2023-109328, and also in the Appendix) examined stratified analyses by region and saw little difference for North American, European or Western Pacific studies. The latter was based on 9 studies, including 8 from Asia and 6 of from China. Overall, no differences were noted in the meta-analysis based on region of publication (i.e., results were similar across all 3 regions).

The following Tier 1 recommended revisions have been combined due to their similarity:

- Panel member commented “Consideration has been given to important study attributes, and the consideration ratings appear overall consistent with (i.e., provide the scientific justification needed for) the overall study confidence level ratings in the draft (e.g., Figures 3-18, 3-27, 3-30, 3-33, 3-35, 3-44, 3-45, 3-47, 3-50, 3-51, 3-52). The overall presentation of study results appears clear and various strengths and limitations are described. However, p. 3–131 (lines 17–21) states [emphasis added], “Overall, 17 of the 31 epidemiological studies with mean birth weight in either/both sex or the overall population detected some deficits in relation to PFHxS exposures (see Table 3-17), although these deficits were at times limited to sex-specific findings (Marks et al., 2019a; Lind et al., 2017; Maisonet et al., 2012) and often were not statistically significant (see Figures 3-20, 3-21, 3-23, and 3-24).” In the absence of statistical significance, at a minimum, EPA cannot say with confidence that a study detected a PFHxS-associated deficit since chance cannot reasonably be ruled out (Tier 1 necessary revision for this cited sentence).” (comment 5 of 9)
- Panel member commented “Many other non-statistically significant results should be more clearly and appropriately described and caveated in the text throughout the draft assessment (some developmental section-specific examples: study CIs include 0 for decreases in the endpoints/-β values discussed on p. 3–133 lines 11, 16 and 19, p. 3–136 lines 4, 6 and 7, p. 3-139 lines 7, 15, 19 and 22, p. 3–159 lines 12–13, p, 3-170 lines 34–36, and numerous other examples; study CIs include 1 for ORs on p. 3-142 lines 27 and 31, p. 3–143 lines 1 and 3, p. 3–154 lines 28, 29, 31, 32 and 35, p. 3–177 line 14, and numerous other examples).” (Comment 6 of 9)
- Panel member commented “Similarly: (1) although p. 3-135 (lines 2-3) state, “Among these 11 studies with results in either boys, girls or both, some birth length deficits were detected in 7 different studies (see Figure 3-29),” Figure 3-29 does not appear to show seven studies with statistically significantly results; and (2) when EPA makes such statements as 11 studies demonstrated birth length deficits (p. 137, lines 36–38), EPA should ensure they have considered statistical significance to reasonably rule out the role of chance in such scientific “demonstrations” (Comment 7 of 9)
- Panel member commented “Not explicitly mentioning the lack of statistically significance results in text/discussion that lacks clarity and full transparency and inappropriately adds greater weight to the reported results in the reader’s mind and the overall WOE for such effects. Throughout the assessment, the lack of statistically significance should be explicitly mentioned when discussing study results so as to not inappropriately add greater weight to the reported results being discussed.” (Comment 8 of 9)

[underlined: EPA Response]: As previously described (see EPA responses under Charge Question 2a) and consistent with the EPA IRIS PFAS protocol and the IRIS Handbook, statistical significance (which can inform random error considerations and help some decision-making) was not the primary determinant of what is being highlighted especially for hazard identification. As with all observational epidemiological data, the role of chance/random error was considered in addition to the more important alternative explanations such as systematic errors. As noted in the EPA IRIS Handbook “However, consideration of the consistency in patterns of results does not require that all findings are statistically significant…A presence of a change that lacks statistical significance can be used to support conclusions of consistency. Nor should all statistically significant results be interpreted as evidence of an effect..” More details on this topic are included in the IRIS PFAS Systematic Review Protocol. For transparency and to address the role of random error (i.e., chance), EPA has consistently displayed effect estimates along with confidence intervals (as the preferred and more informative measure of precision vs. an arbitrary choice of an alpha level denoting statistical significance) and often highlighted the extent of individual study results that were statistically significant and non-significant. More importantly, for evaluations of causality and determining the strength of evidence judgments across body of literature, EPA collectively considered chance along with other source of bias/systematic error as alternative explanations when examining the consistency of associations. As noted above, the recent meta-analysis by Ru et al., 2024 (doi: 10.1136/oemed-2023-109328) and also highlighted in the Appendix, provides more robust estimates of the overall weight of evidence, alternative explanations and [underlined: allows for] more precision in the overall effect estimates.

[underlined: Tier 1 Recommended Revision 9 of 9]: identified one additional study on cerebral palsy for EPA to consider.

[underlined: EPA Response]: The study by (Liew et al., 2014) has been added to Appendix Table B-5 in the revised assessment.

#### Tier 2 Suggested Revisions

[underlined: Tier 2 Suggested Revision 1 of 7]: Panel member “expressed reservations about downgrading studies that did not consider eGFR during pregnancy.”

[underlined: EPA Response]: To clarify, studies that did not collect early sample timing data, as well as those that did not analyze data on sample timing and/or measures of pregnancy hemodynamics, were not downgraded in the Confounding domain. Please see Appendix Section C.1.4 entitled Pregnancy Hemodynamics Background where EPA demonstrates that there is no direct evidence in the literature of confounding of PFHxS and birth weight following adjustment of either or both GFR and albumin level. However, studies that included these a priori considerations in their study design and analysis phases were typically rated higher in the Analysis domain than those that did not.

[underlined: Tier 2 Suggested Revision 2 of 7]: Panel member suggested “add discussion of variability of definitions [preterm] for outcomes in studies to assure reader that all the included studies defined preterm uniformly.”

[underlined: EPA Response]: The assessment defines preterm birth as <37 gestational weeks, the standard definition used in the field, and this is clearly stated in the revised assessment. It is acknowledged that future studies might examine very preterm births (often defined as <32 gestational weeks);, however, none of the currently available studies do so.

[underlined: Tier 2 Suggested Revision 3 of 7]: Panel member suggested “Please consider adding data from the following articles which do have PFHxS data: Nian, M., et al., Association of emerging and legacy per- and polyfluoroalkyl substances with unexplained recurrent spontaneous abortion. Ecotoxicol Environ Saf, 2022. 239: p. 113691. AND Yang, Z., et al., Associations between exposure to perfluoroalkyl substances and birth outcomes: A meta-analysis. Chemosphere, 2022. 291(Pt 2): p. 132909.”

[underlined: EPA Response]: Nian et al., 2022, a case control study of unexplained recurrent spontaneous abortion, is included in the revised assessment (see Appendix B, Table B-5). This study was interpreted by EPA as unlikely to impact conclusions, as it is largely null and the overall weight of evidence is inconsistent with few studies showing increased risks of fetal loss.

With respect to Yang et al. 2022, EPA does not typically use external systematic reviews/meta-analyses as primary support without independent review and validation, and generally only when the results of the large EPA resource investment is likely to have a critical impact on EPA conclusions. However, EPA generally cross-checks references listed in reviews and meta-analyses to ensure comprehensiveness of our literature searches. In this instance, the analysis by Yang et al. failed to include several studies identified by EPA and included in the gestational age evaluation and synthesis.

[underlined: Tier 2 Suggested Revision 4 of 7]: Panel member suggested: “The discussion about pregnancy hemodynamics on p. 223/459 is helpful, and could inform (what I think are debatable) decisions to downgrade pregnancy papers which do not include eGFR considerations.”

[underlined: EPA Response]: EPA has clarified how GFR and other measures were considered in the revised assessment (see details in other comment replies under this charge question).

[underlined: Tier 2 Suggested Revision 5 of 7]: Panel member suggested: “provide additional context (at most a paragraph) on the overall pregnant population variability in “ hemodynamic changes” that this section discusses. Improved clarity on the variability of these changes across gestations during normal pregnancy could better (or not) support the statements and exclusion of epidemiology studies that did not adjust for these factors.

[underlined: EPA Response]: As part of study evaluation, studies were not excluded or downgraded if they did not adjust for pregnancy hemodynamics. This has been clarified this in the revised assessment. As noted in the assessment, there is considerable uncertainty in the literature on the anticipated impact (if any) of hemodynamics on relationships between PFHxS exposures and birth outcomes. Particularly relevant to this comment, Appendix Sections C.1.4 and C.1.8 include a detailed description and evaluation on pregnancy hemodynamics and how PFHxS may change during pregnancy based on the available studies of serial measures. For example, a recent study reported no decrease in PFHxS serum concentration in serial sampling during pregnancy (Chen et al., 2021), while another study (Taibl et al., 2023), limited by disparate sample sizes across trimester sampling, reported increases in PFHxS levels across pregnancy. These findings are in contrast to the other long-chain PFAS which uniformly decreased during pregnancy in the same study. This suggests that maternal physiological changes during pregnancy affect PFHxS differently than other long-chain PFAS, although further research would be needed to better understand these apparent differences.

[underlined: Tier 2 Suggested Revision 6 of 7]: Panel member suggested: to ensure in the future that all health endpoint discussions include a statement about Mechanistic Evidence and Supplemental Information to ensure that this category of evidence had been evaluated for each endpoint even if the statement is that no evidence was found. An example where inclusion of this section would have been important in the development endpoints section, is the discussion on page 3-180 lines 10–17 that thyroid effects are discussed separately yet are of potential mechanistically relevant for the discussion of developmental impacts such as AGD, growth and pup viability.”

[underlined: EPA Response]: Please see prior EPA response on this topic in (see response to Tier 3 Future Consideration 2 of 4 of charge question 1). The synthesis of the developmental effects section was updated to refer readers to the synthesis of the available mechanistic evidence on PFHxS-induced alterations in thyroid hormones, which includes information on potential developmental thyroid effects, in Section 3.2.1.

[underlined: Tier 2 Suggested Revision 7 of 7]: Panel member suggested: “It is important and reasonable to consider menstrual fluid clearance as a specific mechanism in the calculation of total clearance for women of childbearing age. Right now, the estimate of menstrual fluid clearance of 0.033 mL/kg/day is based on a single study by Verner and Longnecker (2015). It is mentioned that this value appears to be consistent with the empirical comparison of PFHxS serum concentrations in men and women by Jain and Ducatman, 2022 (Page 3-33). This description is not sufficient. If possible, efforts should be made to calculate menstrual fluid loss from Jain and Ducatman, 2022, and then compare the value with that from Verner and Longnecker (2015). If a direct calculation is not possible, then further information is needed to justify why it appears to be consistent between these two studies.”

[underlined: EPA Response]: In the revised Toxicological Review, the impact of menstrual associated clearance is now calculated from NHANES data which were also analyzed by Jain and Ducatman (2022), although restricted to never-pregnant women, as described in Sex differences in human PFHxS PK (3.1.7). The resulting clearance is 0.031 mL/kg-d and this is now used instead of the value from Verner and Longnecker.

#### Tier 3 Future Considerations

[underlined: Tier 3 Future Considerations 1of 2]: Panel member commented: ‘Suggestive association (p=VALUE)’ can be used to describe a non-statistically significant association

[underlined: EPA Response]: As discussed in various responses, EPA does not strictly rely on p-values to determine relevance of findings, so such language (suggestive association) is not used; rather, the assessment states that “statistically significance” was based on a p-value of 0.05. Effect estimates and 95% CIs are provided in the developmental section as they are more informative and better allow for comparisons considering consistency, potential for bias, and precision.

[underlined: Tier 3 Future Considerations 2 of 2]: Panel member commented: ‘“Please consider a clear statement that EPA/IRIS is interested in maternal-child studies that begin with pre-pregnancy measures of exposure for developmental outcomes. (This is Tier three because getting the word out could be in other venues than this document.) The fluid shifts of pregnancy will make interpretation of serum biomarkers more difficult unless they are obtained prepregnancy or in the first weeks of pregnancy.”

[underlined: EPA Response]: EPA noted in the published meta-analyses described in Appendix C.1 (Ru et al., 2024) that studies with earlier sampling (including preconception) could help inform the potential impact of hemodynamics.

### G.2.6 Public Comments on Noncancer Hazard Identification: Developmental Effects

Public Comment [underlined: (AWWA)]: “The conclusion that the evidence suggests, but is not sufficient to infer, that PFHxS causes developmental effects in humans is scientifically justifiable. The association may be confounded by pregnancy hemodynamics. In addition, the biological importance of small changes in birth weight (per ln-unit increase in PFHxS) is of uncertain public health relevance. Although some argue that a small decrease in birth weight shifts the population birth weight distribution such that a higher percentage of infants are born with birth weight <2500 grams (the definition of low birth weight), the public health relevance of such a shift is not clear. This is explained in more detail below. The USEPA describes the evidence as slight, “based primarily on consistent evidence for birth weight reductions and coherent findings for other fetal and postnatal weight endpoints, but strength was reduced due to concern for confounding and limited evidence of dose-dependence across most studies with categorical data.” The USEPA evaluated 34 studies of differences in mean birth weight in relation to PFHxS. The agency relied on 26 high or medium confidence studies, of which 14 studies found an inverse association between birth weight and PFHxS exposures (in the total study population or among boys but not girls, or girls but not boys). However, this also means that 12 of the 26 studies (or approximately one-half of high and medium confidence studies) did not find associations between birth weight and PFHxS, so the evidence is better described as inconsistent associations between PFHxS and birth weight.

A meta-analysis conducted by the USEPA (2023c) found a decrease of 7.7 g (95% CI: −14.8 to −0.5) per ln-unit increase in PFHxS. This result (a decrease of approximately 0.3ounces per ln-unit increase) does not have a practical interpretation (a ln-unit increase in PFHxS does not have practical importance). In fact, the USEPA (2023a) also noted that most of the studies did not show exposure-response relationships in categorical analyses, and this factor decreased certainty in the evidence.

Infants born in the Faroe Islands have higher average birth weights than infants born in other European and Scandinavian countries. The population has been described as having birth weight that is near optimum (Olsen and Joensen 1985). Optimum birth weight is the weight associated with the lowest mortality (Wilcox 2001). When compared to other Nordic countries, this phenomenon has been measured since approximately the mid1970s (Olsen and Joensen, 1985). Average birth weight has continued to increase in recent years in the Faroe Islands (Olsen et al. 2023). This increase has occurred despite two reports of small decreases in birth weight in relation to PFAS in two studies of birth cohorts in the Faroe Islands – birth cohort 2 (born in 1994–1995, Xiao et al. 2020) and birth cohort 3 (born 1997–2000, Valvi et al. 2017). Therefore, the biological significance of these reported decreases in birth weight is unknown.

Some have argued (including the USEPA 2023a) that a shift in the mean distribution of birth weight results in a greater proportion of infants born that are of low birth weight and this has practical implications on infant mortality and morbidity. Importantly, the USEPA’s stated interest in birth weight as an outcome is because it is associated with developmental morbidity or mortality; however, these associations may be non-causal (Wilcox 2001). Wilcox (2001) concludes that birth weight is of little utility for measuring infant mortality. Although low birth weight (LBW, <2500 g at birth) has been used in some epidemiological studies as a surrogate for pre-term birth, LBW (as well as intrauterine growth restriction, IUGR) mixes preterm births with smaller infants that are term births. Wilcox (2001) argues persuasively that the emphasis on LBW as a predictor (or a surrogate) of population health is misplaced and the associations between birth weight and mortality (or morbidity, such as cerebral palsy and studies of adult hypertension) reported in many studies are not causal. Wilcox (2001) discusses the LBW paradox (that is, LBW infants in high risk populations have lower mortality than LBW babies born in low risk populations): examples of this paradox include lower mortality in LBW infants born to mothers who smoke when compared to mothers who do not smoke, lower mortality in LBW infants born at high altitudes when compared to LBW infants born at low altitude, lower mortality in LBW Black infants compared to LBW white infants, LBW twins compared to LBW singletons, LBW births in the US when compared LBW births in Norway. Wilcox (2001) concludes that “birthweight is of limited importance as an endpoint in itself, and is inconsequential in the analysis of infant mortality or other outcomes.” Overall, preterm births are the infants that are most at risk for infant mortality or other morbidity. Most studies of pre-term birth and PFAS have reported null associations between PFHxS exposure and pre-term birth (see summary in USEPA 2023a). “

[underlined: EPA Response]: Although the overall comment is supportive of EPA’s conclusions, several of the specific points warrant responses; additional supporting details and discussions on the topics raised in these comments are provided Appendix C of the revised report. First, the 8 gram decrease in birth weight per each ln-unit increase in PFHxS as detailed in EPA’s meta-analysis may seem relatively small in magnitude but would be much larger if extrapolated across the very broad exposure contrasts shown in some of these epidemiological studies. For example, some studies showed some very large PFHxS exposure ranges up to 75 ng/mL in their study populations. [underlined: The synthesis] also notes that the median exposure ranged from 0.16 to 10.36 ng/mL across the 27 studies [underlined: included] in the meta-analysis. Issues related to generalizability of the Faroese population are moot here as publications related to this population did not advance to dose-response for these developmental epidemiological measures. [underlined: For example], the study by Valvi et al. (2017) was not supportive of a decreased birth weight for PFHxS exposures. Hence, why this study did not advance to dose-response. The Xiao et al. (2020) study did show some inverse associations between PFHxS and fetal growth measures (including birth weight). However, their reporting of standardized measures precluded consideration of this study at the dose-response stage given the inability to re-express these data as mean birth weight differences without acquiring additional data from the authors. EPA agrees that there is currently no ideal surrogate measure alone that conveys the totality of potential developmental effects (e.g., fetal growth and gestational duration are indicative of different health effects and associated with other health effects later in life, and while related, they also can be etiologically distinct). Thus, the objective isn’t to identify a measure of fetal mortality. So, EPA advanced birth weight to dose-response as this was considered a highly accurate, reproducible, and reliable measure that represented the most consistent data across many epidemiological studies. It is acknowledged that there are other factors that may result in spatiotemporal shifts in birth weight or higher or lower weight levels in certain populations such as the Faroese. Any factors that are associated with PFHxS exposures and the outcomes of interest (i.e., confounders) are routinely considered as alternative explanations of reported associations by epidemiological investigators as well as by the EPA as part of the assessment of different potential sources of bias. Lastly, while specific mechanistic information on birth weight changes may currently be lacking for PFAS exposures, it remains EPA’s judgment that even small changes in weight at different lifestages including birth ￼.

Public Comment [underlined: (AWWA)]: The three studies that were considered high quality by the USEPA (2023a) in the Toxicological Review (3M 2003, Butenhoff et al. 2009, and Chang et al. 2018) provided no evidence of PFHxS-induced developmental effects apart from small maternal weight changes of unclear biological significance and a litter size decrease in one study that was not dose-dependent (Chang et al. 2018). Overall, the USEPA (2023a) review found no notable effects on maternal health, or on fetal viability, growth or gestation duration. Significantly, the EPA concludes that, “The available animal studies do not provide evidence coherent with the epidemiological observations of effects on fetal growth (i.e., rodent offspring body weights were generally unaffected.” Therefore, the animal data do not provide support for the relevance of the observed epidemiological associations to any actual human health impacts.

[underlined: EPA Response]: The process of evidence integration is outlined in chapter 6 of the ORD Handbook for Developing IRIS Assessments (https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=356370). Please see Section 6.2.2 and table 6-7 for explanation of the different evidence integration judgments and example scenarios.

### G.2.7 External Peer Review Comments on Charge Question 2d (Hepatic Effects)

#### Peer Review Comment Summary

The majority (5 of 9) of the reviewers agreed with EPA’s conclusions. One reviewer recommended revising the evidence stream judgment of animal toxicity to “moderate” based on evidence of increased liver weight, changes in histopathology, and the promotion of fatty liver development. Another reviewer provided multiple Tier 1 and Tier 2 comments on this section, including recategorizing lipid profiles and cholesterol into the hepatic section. Although the reviewer agreed that these changes to the document would not affect the overall conclusions for this section. Another reviewer noted that if cholesterol is recategorized under liver effects, the conclusion should be revised to Evidence Indicates (likely). Another reviewer noted agreement with the above reviewer’s suggested revisions for this section. A reviewer noted agreement that alterations in lipid profiles would be more appropriate in the hepatic section than the cardiometabolic section. A reviewer commented that the long half-life of PFHxS should be considered regarding an “adaptive” hepatobiliary response and if this can be considered benign as a long-term state. Lastly, one reviewer declined to comment on charge question 2d, noting that the topic is outside of his area of expertise. The tiered comments on Charge Question 2d were:

- 38 Tier 1 Recommended Revisions from three reviewers (33 from one panelist)
- 10 Tier 2 Suggested Revisions from three reviewers
- 3 Tier 3 Future Considerations from one reviewer

#### Tier 1 Recommended Revisions

[underlined: Tier 1 Recommended revision 1 of 38]: Panel member commented: “Recommend revising the evidence stream judgement of animal toxicity to moderate based on evidence of increased liver weight, changes in histopathology and promotion of fatty liver development.”

[underlined: EPA Response]: This section was revised to address questions from this reviewer and others on the interpretation of fatty liver and serum markers of hepatic disease. Additional background information and risk of bias considerations were expanded within the synthesis section. After a re-analysis of the available evidence and consideration of strengths and weaknesses of the available evidence, EPA concludes the available animal evidence remains slight. and the evidence integration summary judgment for PFHxS and liver effects is that evidence suggests, but is not sufficient to infer that exposure to PFHxS might cause hepatobiliary system effects in humans given sufficient exposure conditions. Although a health hazard was not identified a POD was calculated for hepatic effects as the evidence base for PFHxS includes well conducted epidemiological studies reporting alterations in serum markers for liver disease, and was considered informative of potential effects relevant to susceptible populations or lifestages. Aspects of the studies which may reduce certainty are presented in the updated synthesis and discussed in the evidence integration section. Additional studies are needed to characterize the effects of long term exposure to PFHxS and whether observed responses progress to adverse effects.

[underlined: Panel Member Recommended Revisions on Related Topics:]

- Reviewer noted that cholesterol is categorized under ‘cardiometabolic’ but is actually a liver effect. If this is determined to be the case then recommend an evidence stream judgment of ‘moderate’ based on consistent findings of increased odd of high cholesterol and increased ALT in adults. If such a revision is adopted the overall conclusion should be revised to Evidence Indicates (likely). (Comment 2 of 38)
- The section should include consideration of cholesterol. Cholesterol is not metabolized in the heart or brain to any important degree. Please switch from considering only downstream effects of liver toxicity on other organs, (cholesterol can affect the heart and vasculature in human populations) to the organ of cholesterol metabolism - the liver. (Comment 3 of 38)
- Commented that the section should include consideration of cholesterol. (Comment 4 of 38)
- Commented that the section should acknowledge the link between PFAS exposure and more people taking cholesterol-lowering medications. (Comment 8 of 38)
- Further discussion about why cholesterol is part of the consideration of liver outcomes. On p. 247/359, about experimental liver evidence, this is where the document does (finally) express awareness that lipid outcomes and bile salt outcomes are liver relevant. Exactly. This kind of 360 degree weight-of-evidence approach is necessary for humans. These are human topics, as part of the consideration of liver. Higher cholesterol is also a nontrivial health outcome for humans. (Comment 13 of 38)
- Associations of PFHxS to cholesterol, LDL cholesterol, and Tier 2) uric acid (and ApoB, bile salts, cytokeratin fractions , and the toxicology experimental evidence of associated metabolic pathways) should be included in the synthesis of liver effects. This will clarify the weight of evidence. (Understanding the sources of bias includes underestimation bias in the case of severely impaired eGFR and any albuminuria, which is also important). (Comment 14 of 38)
- Reviewer noted that cholesterol is categorized under ‘cardiometabolic’ but is actually a liver effect. If this is determined to be the case then recommend an evidence stream judgment of ‘moderate’ based on consistent findings of increased odd of high cholesterol and increased ALT in adults If such a revision is adopted the overall conclusion should be revised to Evidence Indicates (likely). (Comment 23 of 38)
- Hepatocyte lipid accumulation is adverse for a compound that causes elevated lipids and elevated ALT in humans according to Hall Criteria. It is certainly adverse in humans, and it is unwise and without scientific foundation to assume it is unimportant in animal species when we are discussing the same exposure. Further, Hall criteria [Hall et al., 2021] as applied to experimental data are about short-term exposures in the context of understanding short term clinical trials, and humans are not exposed to PFHxS short term (Comment 34 of 38). Steatosis in humans is potentially reversible, but it can also progress to chronic and fatal disease. Further, the demonstration of reactive oxygen species (ROS) effects are adverse. Please review the quotation from (above) from [Hall et al., 2021], where it is clear that a long-term exposure in humans (and damage) with evidence of experimental damage is adverse and not adaptive. (Comment 34 of 38)
- Quoting from the document: p. 255/459 The available mechanistic evidence supports that PFHxS exposure may induce fatty liver disease, but subchronic and chronic duration studies are not available to inform whether the observed PFHxS-induced effects progress to adverse responses (e.g., steatosis and steatohepatitis) in animal models. The authors probably mean to say less reversible responses but even that correction would not sufficiently address the misapplication of Hall criteria for this outcome. They should not imply that the steatosis seen with long half-life PFAS including PFHxS are somehow not adverse because they are potentially reversible. By the same logic, future documents could dismiss a wide range of reversible outcomes across organ system domains including and not limited to altered immune response (from a very long list of potentially reversible outcomes). This is yet another misinterpretation of [Hall et al., 2021]. Steatosis and higher liver enzymes have been seen after PFAS exposures, and the existing evidence does support this as a problem for PFHxS and does not suggest that PFHxS is an exception. We do not know if the problem is reversible in humans after short term exposure, and it would not matter for application of Hall criteria as the half-life is quite long. (Comment 35 of 38)

[underlined: EPA Response]: Section 3.2.4 on hepatic effects was revised to clarify the interpretation of fatty liver, hepatic tissue lipids (e.g., cholesterol and triglycerides), and clinical markers of hepatic disease. Background information on markers of liver disease and the possible hepatic and biliary responses informed by each of them was added to the introduction. The hepatic effects section was reorganized to include a stand-alone subsection presenting the available evidence on hepatic tissue levels of lipids. However, while the available findings on serum lipids were explicitly considered in drawing conclusions regarding hepatic effects, the primary analysis and discussion of the serum lipid data was not moved to the hepatic section.

The primary analysis of serum lipids is retained in the cardiometabolic effects section (see 3.2.6.) in the revised assessment. While changes in serum lipids could potentially be secondary to effects of PFHxS on the hepatic system (e.g., on hepatic metabolic function, noting that mechanistic support for such a potential linkage is currently lacking), increases in serum lipids such as cholesterol and triglycerides are also directly relevant to cardiovascular health. According to the American Heart Association elevated levels of serum cholesterol and triglycerides are well-established risk factors for atherosclerosis; a cardiovascular disease characterized by the formation and growth atherosclerotic plaques (fatty deposits) that are mostly composed of cholesterol (Fryar et al., 2012; Fruchart et al., 2004; American Heart Association, 2022). As outlined in the IRIS PFAS Systematic Review protocol and retained in the revised PFHxS assessment, serum lipid findings are primarily discussed as part of characterizing cardiometabolic effects, while noting the importance of these outcomes in the section characterizing hepatic effects. The serum lipid findings are explicitly considered in drawing the hepatic evidence synthesis conclusions as an indication of potential coherence across biologically related outcomes. This approach of having the primary discussion of serum lipid effects appear as part of cardiometabolic outcomes makes the PFHxS assessment consistent with other recent IRIS assessments, including of other PFAS.

EPA retains use of the Hall considerations (Hall et al., 2012) to aid evaluations (e.g., of adversity) of the hepatic effects evidence in the revised PFHxS Toxicological Review. This approach was outlined in the PFAS Protocol and is consistent with other IRIS Toxicological Reviews of PFAS. After a re-analysis of the available evidence and consideration of the strengths and weaknesses of the available studies, the revised assessment retains the conclusions that the available animal and human evidence provide slight evidence for hepatic effects, and the evidence integration summary judgment remains that the evidence suggests, but is not sufficient to infer, that exposure to PFHxS might cause hepatic system effects in humans. Although a likely health hazard was not identified (IRIS assessments typically do not include dose-response analyses for evidence suggests conclusions (U.S. EPA, 2022b), a POD was calculated for hepatic effects because the evidence base for PFHxS includes well conducted epidemiological studies and the POD was considered potentially informative to decisions regarding the better-supported values (e.g., comparing PODs to inform uncertainty factor selection) or for potential future use in other decision contexts (e.g., providing a sense of the magnitude and uncertainty of potential risks, ranking potential hazards, or setting research priorities) (U.S. EPA, 2005).

Pannel Member Recommended Revisions on Related topics:

- Commented that the section should indicate that biomarker data support hepatoxicity. (Comment 5 of 38)
- Commented that the section should note that alkaline phosphatase and bilirubin are not reasons to ignore ALT data. (Comment 6 of 38)
- Commented that the section should not characterize ALT changes as “small.” (Comment 7 of 38)
- Revise text: alkaline phosphatase data and total bilirubin data should not be understood as contradicting transaminase data. (Comment 10 of 38)
- Total bilirubin measurements are also an awkward way to get at liver damage from an industrial toxin, and use of total bilirubin measures to support or contradict more specific and more sensitive measures are unsatisfactory. Start at the individual level. To understand the source of bilirubin, one needs to assess both conjugated and unconjugated bilirubin, and then to compare their message to other liver biomarkers in order to understand the actual message of a bilirubin measure. One compares them to understand the source, one does not conclude they are somehow “contradictory.” And one does not wait for total bilirubin to rise if there are messages from more sensitive liver biomarkers. One also has to rule out the usually innocuous Gilbert’s syndrome (an inherited metabolic trait associated with higher unconjugated and higher total bilirubin and statistically better health). Bilirubin is two measures that are considering one class of compounds but of two origins. One is mostly affected by liver and gall bladder/bile ducts (direct or conjugated bilirubin), the other (indirect or unconjugated) is affected by what happens in blood and hematopoietic processes or a common inherited genetic variant. From a population perspective, total bilirubin is an insensitive and nonspecific way to look for hepatic toxicity. When bilirubin is also elevated, we think first about a “cholestatic” reason for elevations in ALT. When bilirubin is not elevated, we think about hepatic reasons. We do not think the ALT is incorrect if the bilirubin is not elevated. This assessment is simply imaginary. See for example the StatPearls Continuing Education Activity for liver Function Tests in the National Library of Medicine. https://www.ncbi.nlm.nih.gov/books/NBK482489/ (Comment 11 of 38)
- The assertion that finding no association with alkaline phosphatase allow us to disregard ALT (and other liver biomarker elevations is incorrect. There are two reasons. The first is that it is measuring something overlapping but mostly different, cholestasis (and less commonly bone disease), more often caused by organs related to but different than the liver. The second is fails on the basis of the clear problem of reverse causation. Cholestasis will elevate alkaline phosphatase and lower serum PFAS. (Comment 12 of 38)
- Regarding sentence at p. 233/459 “Alkaline phosphatase (ALP), bilirubin, and γ-glutamyltransferase (GGT) are also routinely used to evaluate potential hepatobiliary toxicity (Hall et al., 2012; EMEA, 2008; Boone et al., 2005).” Necessary revision: Delete the sentence or recognize and clarify the pivot to a new topic. There are two options. One is to decide if the pivot to biliary causes of hepatic problems is important. It may not be necessary. (Comment 16 of 38)
- Regarding sentence at p. 235/459 cited in cell C105: reviewer takes issue with use of word “small” to describe changes in ALT increases. Please see submitted comment for full explanation and background references. (Comment 21 of 38)
- It is not recommended that EPA persist in labeling serum enzyme changes and their effects on humans as small in a public document. And it is not recommended that the wording imply that they are known to be unimportant reviewer takes issue with use of word “small” to describe changes in ALT increases. Please see submitted comment for full explanation and background references. (Comment 22 of 38)
- Regarding sentence in document p235/459; “it is not possible to evaluate whether the small changes in liver enzymes observed in these studies translate to clinical hepatic injury” This statement is unjustified and should be omitted, and the population evidence of hepatic damage noted and discussed in an even-handed way. (Comment 24 of 38)
- In populations, please acknowledge that worse ALT is adverse. If the agency wishes to argue against conclusions concerning the population science of lab tests based on multiple studies that higher ALT is adverse in populations, it needs to do so with science. (Comment 31 of 38)
- Suggested “approach to wording of the revision that permits science and nuance: Please be clear the outcome is adverse and findings consistent with liver damage. Please stop implying that the population alterations are “small” in the absence of representations of per cent changes, how that underestimates the actual distribution of the normal range and known effect (from PFOA) of “small” effects on abnormal values. Somewhere in the document, it could be here, elsewhere, or more than one place, EPA should take a 360 look at lipid, bile acid, and uric alterations as additional evidence, including human data and parallel experimental data concerning liver physiology. If EPA wants to add that the extent and nature of the liver damage needs further clarification concerning most relevant mechanisms and severity, that is fine. What is problematic is a wordsmithing approach to dismissing so many line of evidence.” (Comment 32 of 38)
- Quoting from the document: p. 254/459 “There is also some unexplained inconsistency across studies and incoherence across liver enzymes other than ALT that further reduces the strength of the evidence.” This sentence is misleading. It is mostly a non sequitur, not supported by the literature concerning the use of different biomarkers and should be deleted. ALT is the preferred enzyme for a reason. This is so well known that is the topic of a science direct discussion.” (Comment 33 of 38)
- Above reviewer’s “necessary revisions address directly the questions on: markers of adversity (see comments on supporting the adversity claim when biomarkers are integrated and a clinical lens on long half-life PFAS compounds are considered); where non-quantitative (nor supported) phrases such as “small” changes are used (for example see details on how various biomarker changes are evaluated in the clinic); consistency of hepatic findings from PFHxS within the context of other evaluated PFAS compounds; importance of the rat versus mouse studies in providing evidence of toxicity, see reference Das et al 2017; importance of changes in ALT, ALP and AST need to be further clarified, integrated and aligned with clinical manifestations of hepatic toxicity. Such clinically centered discussion would also aid in the integration of cholesterol changes (now listed under serum lipids in the cardiometabolic section).” (Comment 37 of 38)

[underlined: EPA Response]: The liver section was updated to address comments and recommendations on clinical markers of liver damage. The updated section includes additional background for the clinical markers of liver disease reported in the available epidemiological and toxicological studies and possible hepatic or biliary responses informed by each one. The synthesis was updated to explicitly state that changes in ALT are considered adverse on their own and to remove reference to “small” changes. The revised assessment does not interpret bilirubin and ALP results as contradicting ALT evidence. Additional discussion of coherence with lipids, bile acid, and uric acid was added to the hepatic effects section. See updated synthesis of human and animal evidence on clinical markers of liver disease in Section 3.2.4. In addition, although a health hazard was not identified a POD was calculated for hepatic effects as the evidence base for PFHxS includes well conducted epidemiological studies, and was considered informative of potential effects relevant to susceptible populations or lifestages. As described in the assessment protocol this toxicological review is focused on PFHxS and a qualitative comparative analysis that considers other PFAS” was not performed. However, the liver effects section was substantially updated to reflect comments on the interpretation of fatty liver and clinical markers of liver damage.

The following comments are grouped due to their similarity:

- Commented that the section should desist from using the Hall Criteria for a topic where PFAS are known to adversely affect humans. (Comment 9 of 38)
- Quoting from the document: p. 253/459 .”..the available evidence supports an interpretation that the responses to PFHxS observed in the currently available animal studies are considered adaptive” this unsupported conclusion that toxicological effects are adaptive should be altered or omitted. Invocation of “Hall criteria” as an adaptive response of no importance to the human condition or across species is not appropriate is inappropriate in the context of an exposure that causes changes in ALT and cholesterol and uric acid in humans, consistent with what is also known about PFOA and PFOS. Dismissing toxicological data in this context is a misapplication of both Hall and Hill criteria, where we have ample evidence that PFOA and PFOS cause human liver damage, sufficient evidence that PFHxS cause human ALT and lipid changes (and uric acid changes and ApoB changes and cytokeratin experimental marker changes) as evidence of liver damage, and evidence across animal species that other PFAS raise ALT in experimental settings. (comment 25 of 38)
- State of NJ comments about liver and about Hall criteria are on target. NRDC comments on supplemental data concerning experimental liver outcomes is important. These critiques should lead to revisions in the liver section. (Comment 27 of 38)

[underlined: EPA Response]: to reflect other comments from this reviewer on the interpretation of fatty liver and clinical markers of liver damage. It includes further discussion of histological effects and the confidence in the studies reporting on these effects. A new section on hepatic lipid accumulation was added. EPA retains use of the Hall considerations (Hall et al., 2012) to aid evaluations (e.g., of adversity) of the hepatic effects evidence in the revised PFHxS Toxicological Review. This approach was outlined in the PFAS Protocol (U.S. EPA, 2019b) and is consistent with other IRIS Toxicological Reviews of PFAS. As described in the assessment protocol this toxicological review is focused on PFHxS and a qualitative comparative analysis that considers other PFAS” was not performed. However, the liver effects section was substantially updated to reflect comments on the interpretation of fatty liver and clinical markers of liver damage. The liver effects section was updated.

Related comments from same panelist:

- Update number of epidemiology studies cited on p. 233/459 “Thirteen epidemiology studies (reported in 14 publications) report on the relationship between PFHxS exposure and liver effects, primarily serum liver enzymes” (Comment 15 of 38)
- Add the following relevant studies to liver section: ref #42-#49[Kim et al., 2023; Yun, et al., 2023; Borghese et al., 2022; Dai et al., 2020; Cusi et al., 2014; Bassler et al., 2019; Ma et al., 2023; and Chen et al., 2023] as listed in document. (comment 17 of 38)

[underlined: EPA Response]: Some of the references submitted by the panelist had already been added to the assessment based on previous sources of new literature (e.g., (Kim et al., 2023b; Borghese et al., 2022)). The remaining literature highlighted by the panelist on hepatic effects was screened against the assessment PECO criteria (see PFAS protocol (U.S. EPA, 2019b)) and any newly identified studies meeting PECO were included in the new studies Table B-5 in Appendix B. Briefly, new studies were not expected to influence the hepatic conclusions.

[underlined: Tier 1 recommendation 18 of 38]: Panelist commented: Please also pay attention to NRDC external comments about missing studies on this topic. (Comment 18 of 38)

[underlined: EPA Response]: Studies suggested by NRDC were considered, screened against the assessment PECO criteria, and incorporated as appropriate, primarily in the appendix table but in some cases (e.g., studies of breastfeeding duration, bone mineral density, and hepatic effects in humans) in the assessment synthesis.

[underlined: Tier 1 recommendation 19 of 38]: Panelist commented: “Quoting from the document: p. 235/459 Given the consistency of direction of association for ALT across most of the studies in adults, there is some indication that PFHxS exposure may be associated with hepatic effects. Suggested revision: A. Include all the studies.”

[underlined: EPA Response]: The text was revised for clarity. The use of “most studies” was not intended to suggest that only some studies were considered, but rather than most studies found a positive association with ALT.

The following comments are grouped due to their similarity (some comments were summarized for brevity please see Final PFHxS Peer Review Summary for full comments):

- Quoting from the document: p. 253/459 .”..the available evidence supports an interpretation that the responses to PFHxS observed in the currently available animal studies are considered adaptive” this unsupported conclusion that toxicological effects are adaptive should be altered or omitted. Invocation of “Hall criteria” as an adaptive response of no importance to the human condition or across species is not appropriate is inappropriate in the context of an exposure that causes changes in ALT and cholesterol and uric acid in humans, consistent with what is also known about PFOA and PFOS. Dismissing toxicological data in this context is a misapplication of both Hall and Hill criteria, where we have ample evidence that PFOA and PFOS cause human liver damage, sufficient evidence that PFHxS cause human ALT and lipid changes (and uric acid changes and ApoB changes and cytokeratin experimental marker changes) as evidence of liver damage, and evidence across animal species that other PFAS raise ALT in experimental settings.
- State of NJ comments about liver and about Hall criteria are on target. NRDC comments on supplemental data concerning experimental liver outcomes is important. These critiques should lead to revisions in the liver section.

[underlined: EPA Response]: As described in the assessment protocol this toxicological review is focused on PFHxS and a qualitative comparative analysis that considers other PFAS” was not performed. However, the liver effects section was substantially updated to reflect comments on the interpretation of fatty liver, including a new section on hepatic lipid accumulation, and clinical markers of liver damage. The section now includes further discussion of histological effects and the confidence in the studies reporting on these effects.

[underlined: Tier 1 Recommendation 26 of 38]: Panelist commented “At a minimum, there should be discussion that assumptions that changes are adaptive become less defensible when humans have deleterious outcomes in the same organ and the same pathways are affected, and the human exposures are long term.”

[underlined: EPA Response]: The panelist is describing an aspect of coherence looking across evidence streams, where findings in one evidence stream can reduce the uncertainties that exist in a another. This is an explicit part of EPA’s framework for evidence integration (see IRIS Handbook (U.S. EPA, 2022b)). As described in prior EPA responses, important edits were made to the human and animal synthesis sections on hepatic effects. In addition, EPA re-evaluated the potential for cross-stream coherence to strengthen the judgments. However, because substantial uncertainties still remain regarding the human evidence as well as the animal evidence, and because the results for individual outcomes across streams are often heterogenous and no sufficiently supported MOA or identified key event(s) exist to better connect the two evidence streams, the same judgments are retained. Namely, the revised assessment retains judgments of slight evidence for each evidence stream and a determination that the linkage between evidence streams is insufficient to support a stronger hazard call. Given the strong possibility that PFHxS might affect the liver in ways observed for other PFAS if more evidence were available, this highlights a topic area that may warrant additional research in the future.

- Two related comments from same panelist:
  ○ The following sentence is problematic because it represents a change in context, in which a new topic is used to reflect on a previous topic without clarification. Quoting from the document p. 254/459 “The available evidence suggests but is not sufficient to infer that exposure to PFHxS might cause hepatobiliary system effects in humans given sufficient exposure conditions.” (Comment 28 of 38)
  ○ Quoting from the document p. 254/459 The available evidence suggests but is not sufficient to infer that exposure to PFHxS might cause hepatobiliary system effects in humans given sufficient exposure conditions. “ This sentence has some “move the goalpost” characteristics. The topic has been liver and hepatocyte, not liver and mostly gall bladder and biliary and hepatic ducts. If we must expand the discussion, please write about the evidence for gall bladder, bile duct, pancreatic duct, independently of liver, and do not assume that the ALT findings are contradicted by other findings. EPA authors do seem to be aware that they have branched out into the biliary topic, and used a different organ set (bile duct, gall bladder, pancreatic duct) to come to weight of evidence conclusions about liver. If the goal is to have separate sections about liver and biliary, or liver specifically and “hepatobiliary,” that could work. With evidence in the timeframe of this EPA work, other organs would probably not be reliably implicated.” (Comment 29 of 38)

[underlined: EPA Response]: The organization and types of evidence considered in this section are consistent with practices applied to all other IRIS PFAS assessments. Additional background text was added to provide context for responses on serum markers of liver disease and the possible hepatic and biliary responses informed by each of them was added to the introduction section of the hepatic effects synthesis. The characterization in the sentence quoted above is standard for EPA’s description of evidence integration judgments when the hazard category determined by EPA is “evidence suggests” (but is not sufficient to infer). Please see the ORD Staff Handbook for Developing IRIS Assessments (U.S. EPA, 2022b).

[underlined: Tier 1 Recommendation 30 of 38]: Panelist recommended: “Quoting from the document. p. 254/459 and Table 3-23 The available evidence on PFHxS-induced hepatic effects in humans is considered slight. There is some evidence of an association between PFHxS exposure and hepatic effects in human studies that is based on largely consistent associations with liver biomarkers (primarily small increases in ALT, a specific biomarker of potential liver injury) in the blood in multiple studies of adults. It is not clear what is meant by ‘slight’ that is different from “largely consistent.” The normal distribution of ALT and the effect of changes on abnormal values has been ignored. Further, it appears that available literature has been ignored (see references provided). Cholesterol and other biomarkers have been omitted. The population public health significance of ALT has been ignored. This sentence is insupportable based on the literature.”

[underlined: EPA Response]: “Slight” is one of the terms used for Evidence Synthesis judgments (Robust, Moderate, Slight, Indeterminate) as described in the IRIS Handbook and the IRIS PFAS Systematic Review Protocol. The definition for Slight states “One or more studies reporting an association between exposure and the health outcome, but considerable uncertainty exists and supporting coherence evidence is sparse.” The reviewer has pointed out considerations that could be judged to increase certainty in the evidence base,, which the text has been revised to acknowledge. However, with updates to the literature and the synthesis since the peer review version, the evaluation of the potential for confounding by other PFAS was also expanded and it was concluded that there is substantial concern for confounding by other PFAS such as PFNA and PFOA. This source of considerable uncertainty prevented upgrading the evidence to “Moderate.”

[underlined: Tier 1 Recommendation 36 of 38]: Panelist recommended: This reviewer was convinced by the detailed clinical and mechanistic evaluation provided by Dr. Ducatman that numerous Tier 1 Necessary revisions are necessary in this section on hepatic effects. These suggested revisions were accomplished by using a clinical informed systems based evaluation of the hepatic effects examining across species the evidence for the various biomarkers of hepatic effect. Additionally, Dr. Ducatman provided excellent examples of how looking across the various PFAS compounds and incorporating a comparative toxicological approach…”

[underlined: EPA Response]: The liver effects chapter was revised to address questions related to the interpretation of clinical markers of liver disease, and tissue and serum levels of lipids and cholesterol (please see responses to panelist comments grouped above). Background information on markers of liver disease and the possible hepatic and biliary responses informed by each of them was added to the synthesis. These suggested revisions were accomplished by using a clinical informed systems based evaluation of the hepatic effects examining across species the evidence for the various biomarkers of hepatic effects. The mechanistic section was updated and includes new MOA figure to visually outline potential cellular/molecular pathways informed by the available evidence. As described in the assessment protocol this toxicological review is focused on PFHxS and a qualitative comparative analysis that considers other PFAS was not performed (U.S. EPA, 2019b). In addition, although a health hazard was not identified a POD was calculated for hepatic effects as the evidence base for PFHxS includes well conducted epidemiological studies, and was considered informative of potential effects relevant to susceptible populations or lifestages and to better allow future research and comparison.

[underlined: Tier 1 Recommendation 38 of 38]: Panelist recommended: In the opinion of this reviewer, Dr. Ducatman’s integrated clinical and mechanistic evaluation has provided an essential and robust platform which details the Tier 1 necessary revisions for this section to clearly state that “unequivocally that the human and experimental data, considered separately or together, indicate the existence of hepatotoxicity, consistent with other long half-life PFAS.” (Dr. Ducatman’s recommended revised statement). CLARIFICATION: To address the collective information for the existence of hepatotoxicity when both the human clinical and experimental data are considered. It is to also acknowledge that this is consistent with other PFAS related compounds that have long half-lives. This revision would impact how the EPA synthesizes the evidence for hepatic effects and having done so recommends that this integration is supportive of hepatotoxicity. I list the factors that need to be included in these revisions as bullet points in this text. (see full PFHxS peer review report for additional comment details)

[underlined: EPA Response]: As described above the hepatic effects chapter’s synthesis of epidemiological, toxicological, and mechanistic effects was updated in response to a reviewer’s comments. The suggested revisions were accomplished by using a clinical informed systems based evaluation of the hepatic effects examining across species the evidence for the various biomarkers of hepatic effect. Revisions were intended to clarify the interpretation of fatty liver, serum lipids/cholesterol, and clinical markers of hepatic disease. As described in the assessment protocol this toxicological review is focused on PFHxS and a qualitative comparative analysis that considers other PFAS was not performed (U.S. EPA, 2019b). Background information on markers of liver disease and the possible hepatic and biliary responses informed by each of them was added to the introduction section of the hepatic effects synthesis. For the synthesis of fatty liver effects, the hepatic effects chapter was reorganized to include a stand-alone section presenting the available evidence on hepatic tissue levels of lipids and cholesterol. For evidence integration EPA is retaining use of Hall considerations (Hall et al., 2012) to evaluate the evidence. This approach was outlined in the PFAS Protocol and is consistent with other IRIS Toxicological Reviews of PFAS. After a re-analysis of the available evidence and consideration of strengths and weaknesses of the available studies EPA concludes the available animal and epidemiological evidence is considered slight, and the evidence integration summary judgment for PFHxS and liver effects is that evidence suggests, but is not sufficient to infer that exposure to PFHxS might cause hepatobiliary system effects in humans given sufficient exposure conditions. Although a health hazard was not identified a POD was calculated for hepatic effects as the evidence base for PFHxS includes well conducted epidemiological studies, and was considered informative of potential effects relevant to susceptible populations or lifestages.

#### Tier 2 Suggested Revisions

[underlined: Tier 2 suggestion 1 of 10]: Panel member commented: animal studies, mice and especially specifically bred humanized mice and rats should be discussed separately based on the known sex differences in metabolism, which will be a function of species-specific relationships of sterol hormones to kidney performance as regards PFAS excretion affecting half-lives.

[underlined: EPA Response]: Studies that used genetically modified animal models are discussed separately for evidence integration in the updated draft. Sex differences in metabolism are also discussed in the hepatic effects chapter. To avoid redundancy the reader is referred to pharmacokinetics section for more detail (Section 3.1).

[underlined: Tier 2 suggestion 2 of 10]: Panel member commented “Quoting from the document: p. 235/459 “Given the consistency of direction of association for ALT across most of the studies in adults, there is some indication that PFHxS exposure may be associated with hepatic effects.” This deserves a statement less broad than “may” and “some indication” which can mean about anything.”

[underlined: EPA Response]: The text was revised to emphasize that the association was observed in the majority of studies in adults.

[underlined: Tier 2 suggestion 3 of 10]: Panel member commented Under analogy, please consider that the findings are also consistent with PFOA and PFOS, meeting Hill “criteria” (Hill, 1965) for analogy, including a very well done meta-analysis by [Costela et al., 2022] for PFOA

[underlined: EPA Response]: The use of surrogate PFAS with richer evidence based (e.g., PFOA and PFOS) to inform PFHxS and other PFAS with modest evidence bases is work that EPA is currently investigating as part of the EPAs PFAS Strategic Roadmap to advance the understanding around PFAS chemicals. The grouping of PFAS is hindered by lack of data. To address the need, EPAs Center for Computational Toxicology and Exposure (CCTE) has developed a chemical category approach that can be applied to facilitate characterization by a chemical structure (Patlewicz et al., 2022). EPAs Center for Public Health and Environmental Assessments (CPHEA) has developed systematic evidence maps (SEM) to collect and inventory the current data on thousands of PFAS. The SEM inventory the available toxicity data across broader classes of PFAS in parallel with tiered toxicity testing. The SEM highlight data gaps and fit-for -purpose assessment opportunities for emerging PFAS of concern (Radke et al., 2022; Carlson et al., 2022). EPA has also partnered with the National Institute of Health (NIH) to develop tiered toxicity testing strategies to fill data gaps and inform decisions on grouping and prioritization. The IRIS Toxicological Review of PFHxS included a summary of hazard conclusions across published EPA PFAS human health assessments (Section 4.1 Table 4-1). As described in the assessment protocol this toxicological review is focused on PFHxS and a qualitative comparative analysis that considers other PFAS was not performed (U.S. EPA, 2019b). The liver effects section was updated to reflect comments on the interpretation of fatty liver, clinical markers of liver disease, and serum lipids, including derivation of a POD for informational and comparative purposes based on ALT. Please see additional details in prior EPA responses.

[underlined: Tier 2 suggestion 4 of 10]: Panel member commented “Please consider if evidence of PFHxS damage to hepatocytes alone or in mixture with other PFAS is relevant [Ojo, A.F., C. Peng, and J.C. Ng, Genotoxicity assessment of per- and polyfluoroalkyl substances mixtures in human liver cells (HepG2). Toxicology, 2022. 482: p. 153359]. Adaptive vs. adverse discussion.”

[underlined: EPA Response]: A mixtures assessment is outside the scope of the assessment. Please see the PFAS Protocol available at: https://iris.epa.gov/document/&deid=345065. The effects of single exposure to PFHxS reported in Ojo et al. (2021) are presented in the mechanisms section and considered in drawing EPA judgments.

[underlined: Tier 2 suggestion 5 of 10]: Panel member commented Table 3-23 is the evidence profile table for hepatic effects, which among other information contains factors that increase and decrease certainty along with evidence stream (i.e., human, animal, mechanistic) judgments/rationales and a summary judgment. Obviously, the text of the document (Section 3.2.4) also contains information relevant to the WOE for hepatic effects. This section concludes (p. 3–217, lines 1–3) that, “The available evidence suggests but is not sufficient to infer that exposure to PFHxS might cause hepatobiliary system effects in humans given sufficient exposure conditions. This is due to limitations in the available evidence that introduce significant uncertainty (see Table 3-23).” I concur with EPA’s overall determination. However, where not provided, a potential improvement for the hazard identification WOEs in the draft would be a discussion of relevant effects caused by other PFAS.

[underlined: EPA Response]: As described in the PFAS Protocol (U.S. EPA, 2019b) this toxicological review is focused on PFHxS and a qualitative comparative analysis that considers other PFAS was not performed. Please see the PFAS Protocol (U.S. EPA, 2019b). However, previous PFOS and PFOA mechanistic analyses were considered in the development of the proposed mechanistic pathway for PFAS-induced noncancer liver effects (Section 9.2 and Figure 9-1 of the PFAS protocol (U.S. EPA, 2019b)), and common pathways activated by PFHxS were also noted (see figure 3-65 in the hepatic effects section [3.2.4] of the Toxicological Review). Furthermore, a hazard comparison across published EPA PFAS assessments (that includes hepatic responses) is presented in table 4-1 (Section 4.1) of the PFHxS toxicological review.

[underlined: Tier 2 suggestion 6 of 10]: Panel member commented that associations between PFHxS with cholesterol, LDL cholesterol, and uric acid should be included in the hepatic effects section

[underlined: EPA Response]: The primary analyses of the estimated glomerular filtration rate (eGFR) and uric acid findings are both presented in the kidney chapter (See 3.2.10). The synthesis was updated to discuss these two outcomes separately. The updated text was also revised to reflect that reverse causation could attenuate associations. As uric acid findings also inform hepatic effects, the evidence integration analysis for liver effects also considers uric acid findings in the updated draft. The updated text was also revised to reflect that reverse causation could attenuate associations.

The evidence integration analysis for liver effects also considers uric acid findings in the updated draft. Serum lipids/cholesterol are described in the cardiometabolic effects chapter (see 3.2.6 and previous EPA responses on this topic above in Appendix G.2.7) as they are considered well-established risk factor for cardiovascular disease including atherosclerosis (Fryar et al., 2012; Fruchart et al., 2004; American Heart Association, 2022). New language was added in Sections 3.2.4 and 3.2.6 of the revised assessment to be more explicit about potential linkages between hepatic effects and changes in cholesterol.

[underlined: Tier 2 suggestion 7 of 10]: Panel member commented “Alterations of lips profiles would be more appropriate for the hepatic section, as opposed to the cardiometabolic section.”

[underlined: EPA Response]: As described above Section 3.2.4 on hepatic effects was revised to clarify the interpretation of fatty liver, hepatic tissue lipids (e.g., cholesterol and triglycerides), and clinical markers of hepatic disease. The hepatic effects section was reorganized to include a stand-alone subsection presenting the available evidence on hepatic tissue levels of lipids. The primary analysis of serum lipids is retained in the cardiometabolic effects section (See 3.2.6.) in the revised assessment. While changes in serum lipids could potentially be secondary to effects of PFHxS on the hepatic system (e.g., on hepatic metabolic function, noting that mechanistic support for such a potential linkage is currently lacking), increases in serum lipids such as cholesterol and triglycerides are also directly relevant to cardiovascular health.

[underlined: Tier 2 suggestion 8 of 10]: Panel member commented: “The Agency reviewed the evidence for hepatotoxicity of PFHxS and found that the evidence suggests but is not sufficient to infer that exposure to PFHxS could cause hepatobiliary effects in humans given sufficient exposure conditions. Their conclusion is based on a thorough examination and articulation of data from human and animal studies. The Agency acknowledges that PFHxS is associated with small changes in some liver enzymes in humans and that this is also found in animal studies. Moreover, mechanistic studies provide a plausible pathway by which adverse liver effects may occur. The Agency considers whether the evidence as revealed in the literature can be taken to infer an adverse effect or whether the observed effects are indicative of an adaptive response. Although the Agency cites Hall et al. 2012, it is not clear that the Agency has considered the very long half-life of PFHxS for this particular endpoint. Is a permanent state of “adaptiveness” reasonable to consider benign? It would be useful for the Agency to overtly address this point.”

[underlined: EPA Response]: The section describing considerations of potentially adaptive versus adverse responses was updated in response to this and other comments on this topic to provide further context on the available evidence. Although a health hazard was not identified a POD was calculated for hepatic effects as the evidence base for PFHxS includes well conducted epidemiological studies, and was considered informative of potential effects relevant to susceptible populations.

[underlined: Tier 2 suggestion 9 of 10]: Panel member commented: “ Alter sentence on p. 235/459 for clarity: “ However, there is still some uncertainty due to the small or imprecise nature of some ALT increases as well as the inconsistency of results for other liver enzymes.”

[underlined: EPA Response]: The text was revised as suggested.

[underlined: Tier 2 suggestion 10 of 10]: Panel member commented: Overall, the draft document’s section summarizing the potential mechanistic pathways for adverse hepatic effects is comprehensive and appropriately supported by the available literature. Given the limitations of both the human and animal studies on this topic, the stated conclusion is reasonable and scientifically justified. I agree that the document could be strengthened by a stricter delineation of biomarkers that are ascribable hepatic injury alone (the transaminases, ALT and AST) versus those related to the biliary system (GGT, alkaline phosphatase, and bilirubin, with a caveat noting that they could also be sourced from other organs and thus are less specific).

[underlined: EPA Response]: Section 3.2.4 on hepatic effects was revised to clarify the interpretation of fatty liver, hepatic tissue lipids (e.g., cholesterol and triglycerides), and clinical markers of hepatic disease. Background information on markers of liver disease and the possible hepatic, biliary, and other organ (e.g., bone disease) responses informed by each of them was added to the introduction of this section.

#### Tier 3 Future Considerations

[underlined: Tier 3 Future considerations 1 of 3]: Panel member commented: “Consideration of alkaline phosphatase could have merit in a different context. If EPA wants to have a section on gall bladder, or on the complexities of evaluating cholestasis in either the biliary system or less commonly liver, and comparing it to alkaline phosphatase from bone sources, that could be beneficial. Otherwise, this is a confusing topic and potentially harmful if presented without clarifications about the different sources and implications, as well as the likelihood that causes of higher serum alkaline phosphatase are also likely causes of greater fecal PFHxS excretion.”

[underlined: EPA Response]: The hepatic effects chapter (3.2.4) was revised to clarify the interpretation of different clinical markers reported in the available studies. Background information on markers of liver disease and the possible hepatic and biliary responses informed by each of them was added to the synthesis. Other physiologic alterations (e.g., in bone) which may also impact these clinical markers are described in the synthesis.

[underlined: Tier 3 Future considerations 2 of 3]: suggestion about epidemiologic approach to liver data. EPA downgraded articles due to the inclusion (lack of exclusion) of hepatitis patients. However, this is an attenuation bias as regards PFAS. (Participants with infectious hepatitis can have liver disease with abnormal liver markers, no reason to have higher PFAS and plenty of reasons to have lower PFAS if there are hepatorenal sequelae.) This shortcoming will logically lead to the possibility of underestimation bias). Yet downgraded articles detected relevant associations. Is it good to dismiss positive (adverse) associations that may be underestimated? Would it be better to include these articles and discuss the potential for bias? This is a policy question for EPA.

[underlined: EPA Response]: To clarify, studies were not excluded from the review for including hepatitis patients. The text in question seems to refer to the discussion of NHANES studies in the hepatic section. When multiple studies have overlapping populations, like the multiple analyses of NHANES data that include overlapping years, EPA selected a primary study to include in the heat maps. The other studies are not excluded and were reviewed to determine whether they provide additional information to the primary study. The reason for this is to avoid overweighting a study population in the synthesis by presenting multiple analyses of the same population as independent. In this case, the text describes the differences between the NHANES analyses, but does not state that any are excluded. The text was revised to reflect that the inclusion criteria refers to author- defined criteria for their analyses.

[underlined: Tier 3 Future considerations 3 of 3]: In the discussion of biomarkers, the future goal is to understand the biomarkers and their function, and to stay on task for the organ and biomarker match. The finding of adversely affected ALT is not lessened by the other findings that are less specific and sensitive to the hepatocyte. These additional findings for other biomarkers such as alkaline phosphatase do have meaning and do assist interpretation, they do not lessen importance of ALT (or AST).

[underlined: EPA Response]: As described in responses to the tier 1 recommendations above in Appendix G.2.7, additional background and context were added for the synthesis of the liver chapter to provide context.

### G.2.8 Public Comments on Noncancer Hazard Identification: Hepatic Effects

Public Comment [underlined: (AWWA)]: The conclusion that the human evidence suggests, but is not sufficient to infer, that PFHxS causes hepatic effects is scientifically justifiable. Of the 10 medium confidence epidemiological studies identified by the USEPA, five studies in adults showed small positive associations between serum alanine aminotransferase (ALT) and PFHxS (Liu et al. 2022; Gleason et al. 2015; Cakmak et al. 2022; Salihovic et al. 2018; Jain and Ducatman 2019). Three studies in children showed small non-statistically significant inverse associations or no association between serum ALT and PFHxS (Mora et al. 2018; Attanasio 2019; Stratakis et al. 2020). The same set of studies reported inconsistent results (direction of effect) for other liver enzymes and biomarkers (aspartate aminotransferase, alkaline phosphatase, γ-glutamyltransferase, and bilirubin) and PFHxS concentrations. There were no studies of PFHxS and liver disease in adults; one study in children reported more severe non-alcoholic fatty liver disease (NAFLD) with PFHxS exposure (Jin et al. 2020). However, Jin et al. (2020) included only children with NAFLD and the study results are not generalizable to other populations.

[underlined: EPA Response]: Although a response is not necessary, it is noted that, in addition to the updates outlined above in response to the peer reviewer comments, EPA also updated the hepatic effects section to provide additional background and context on clinical markers of liver disease and NAFLD.

Public Comment [underlined: (AWWA)]: The evidence of liver effects from animal studies is of questionable human relevance. The mode of action for the liver effects of PFHxS described in the Toxicological Review is consistent with modes of action for the liver effects of many other chemicals, referred to as peroxisomal proliferators. In particular, the liver effects of PFOA have been shown to involve activation of the same multiple, related nuclear receptors including PPARα, PPARγ, CAR, FXR, LXR, and PXR (Andersen et al. 2021). However, humans and rodents have been shown to have strikingly different responses, both quantitatively and qualitatively, to this lipid-related receptor activation. In both species, there is a core response leading to upregulation of a family of genes controlling fatty acid processing; however, in the rat but not the human, there is a secondary pathway controlled by PPARα that makes the cells more responsive to proliferation and subsequent toxicity (McMullen et al. (2020). Therefore, the effects observed in animals do not provide any support for the relevance of the observed epidemiological associations to any actual human health impacts.

[underlined: EPA Response]: The mechanistic analysis for PFHxS-induced liver effects is described in Section 3.2.4. (see mechanistic evidence and supplemental information) and considered evidence on several cellular/molecular pathways. The process of evidence integration and impact of mechanistic evidence is outlined in chapter 6 of the ORD Handbook for Developing IRIS Assessments (U.S. EPA, 2022b). Please see Section 6.2.2 for explanation of the different evidence integration judgments and example scenarios. The mechanistic evidence analysis in this Toxicological Review was focused on PFHxS studies. As described in the PFAS Protocol (U.S. EPA, 2019b) this toxicological review is focused on PFHxS and a qualitative comparative analysis that considers other PFAS was not performed. The mechanistic analysis described in the hepatic effects section (3.2.4) employed the mode of action analysis framework to evaluate all potential mechanistic pathways informed by the available PFHxS studies using wild type and genetically modified rodent models and cell culture studies on human hepatocyte HepG2 cells. This includes activation of PPARα and other nuclear receptor pathways (specifically CAR/PXR and PPARγ). As described in the mechanistic and evidence integration sections the available “evidence indicates a role for PPARα-dependent and -independent pathways in the MOA for noncancer liver effects of PFHxS. Limited in vitro studies suggest some responses may be activated in human molecular/cellular models.” However, limitations were also identified and include inconsistencies in experiments using human HepG2 cells and few studies using in vivo models. Future studies need to address these uncertainties to provide clarification on the role of PPARα (and other cellular/molecular pathways) in PFHxS-induced hepatic effects.

### G.2.9 External Peer Review Comments on Tier 2e (Neurodevelopmental Effects)

#### Peer Review Comment Summary

The majority of the reviewers (6 of 9) agreed with EPA’s conclusions. One reviewer recommended revising the evidence stream judgment of observational evidence to “moderate” based on consistent findings in observational studies of increased ADHD in children. One reviewer requested clarification on the meaning of the term “imprecise” in the context of this section. Lastly, one reviewer declined to comment on charge question 2e, noting that the topic is outside of his area of expertise. The tiered comments on Charge Question 2e were:

- 1 Tier 1 Recommended Revisions
- 3 Tier 2 Suggested Revisions from two reviewers
- 2 Tier 3 Future Considerations from two reviewers

#### Tier 1 Recommended Revisions

[underlined: The following Tier 1 and Tier 2 comments were grouped due to their similarity]:

- Commented that EPA should clarify what “imprecise” means in the context of this section. (Tier 1 comment 1 of 1)
- The Agency identified 17 epidemiological studies and 2 animal studies that focused on evaluating relationships of interest between PFHxS exposure and various measures of neurobehavioral effects. They conclude that there is slight evidence based on human studies and that the animal studies are indeterminate. Although many of the human studies show a positive relationship between PFHxS and neurobehavioral endpoints, the Agency concludes that the evidence is not sufficient in part because the measures are “imprecise.” It is not clear what “imprecise” means. If this means that confidence intervals are too broad, it would be useful if this is explained. Moreover, if this is the case, it would be useful if the Agency described a theoretical basis for consideration of confidence intervals around the specific endpoints evaluated and what constitutes a departure from what might be considered a normal variance. (Tier 2 comment 3 of 3)

[underlined: EPA Response]: Text was revised to clarify the use of “imprecision,” specifically that confidence intervals were wide around an effect estimate and there was a lack of statistical significance in this instance.

#### Tier 2 Suggested Revisions

[underlined: Tier 2 Suggested revisions 1 of 3]: Panel Member Suggested Revision: “Recommend revising the evidence stream judgement of observational evidence to moderate based on consistent findings in observational studies of increased ADHD in children. “

[underlined: EPA Response]: It is noted that this represents a minority opinion among the eight experts who provided comments. However, EPA re-reviewed the available evidence. Given the inconsistency among studies of ADHD diagnosis, with the single prospective study of ADHD diagnosis reporting an inverse association, EPA retains the slight judgment for neurodevelopmental effects in the revised assessment.

[underlined: Tier 2 Suggested revisions 2 of 3]: Panel Member Suggested Revision: Include this study (It will not change the conclusions, only reinforce them and broaden the area of consideration.): Vilhelmsson, A., et al., Exposure to per- and polyfluoroalkyl substances in early pregnancy and risk of cerebral palsy in children. Sci Total Environ, 2023. 899: p. 165622.

[underlined: EPA Response]: This study was considered as described in prior EPA responses and added to Appendix Table B-5.

#### Tier 3 Future Considerations

[underlined: Tier 3 Future considerations 1 of 2]: Panel member commented: Future animal studies should investigate neurodevelopmental effects of PFHxS alone and as commonly observed mixtures.

[underlined: EPA Response]: EPA notes that this comment is aimed at the research community as the IRIS Program does not conduct experimental studies.

[underlined: Tier 3 Future considerations 2 of 2]: Panel member commented: EPA’s text on reverse causation: While the statement is correct for reverse causation, reverse causation is not the most likely concern, and it is unclear why reverse causation is the only bias discussed. Likely concerns include relationships of sociodemographic variables to serum PFAS and to measured outcomes that may lead to unmeasured confounding despite adjustment.

[underlined: EPA Response]: Other sources of bias were considered during the study evaluations. Generally only sources of bias considered important to interpreting the reported results are highlighted in the synthesis. In this case, reverse causation was mentioned because of the use of cross-sectional measurements.

### G.2.10 Public Comments on Noncancer Hazard Identification: Neurodevelopmental Effects

Public Comment [underlined: (AWWA)]: “Epidemiological studies report inconsistent associations between PFHxS exposure and ADHD or related behaviors. The epidemiological evidence is inadequate to conclude that PFHxS exposure causes neurodevelopment effects in humans.”

[underlined: EPA Response]: As described in the revised assessment, while the evidence for neurodevelopmental effects is inconsistent, there are sufficient associations for EPA to retain a judgment of slight human evidence.

Public Comment [underlined: (AWWA)]: There is no animal evidence of neurodevelopmental effects from PFHxS. To the contrary, while there were no high-confidence studies, there were two medium-confidence studies (Butenhoff et al. 2009; Ramhoj et al. 2020) that observed no effects of PFHxS on Functional Observational Battery (FOB) parameters, motor activity, or learning and memory.

[underlined: EPA Response]: The (Butenhoff et al., 2009) and (Ramhøj et al., 2020) studies are described in the neurodevelopmental effects section. The evidence from the available PFHxS studies on neurodevelopment is considered indeterminate, as described, and justified in Section 3.2.5 of the revised assessment.

### G.2.11 External Peer Review Comments on Charge Question 2f (Cardiometabolic Effects)

#### Peer Review Comment Summary

The reviewers generally agreed with EPA’s conclusion. However, in line with comments from section 2c several reviewers agreed that cholesterol and serum lipids in this section should be integrated with the hepatic section. One reviewer recommended revising the evidence stream judgment of observational evidence to “moderate” based on consistent findings related to increased odds of high cholesterol in adults, however the reviewer noted that this revision does not apply if the change to consider cholesterol effects under liver effects is implemented. One reviewer also suggested adding ApoB outcomes. Further, the reviewer thought EPA overemphasized the potential for reverse causation or confounding from diet. This reviewer also commented that the statement, “evidence for other cardiovascular-related effects is mostly null, which raises questions about the adversity of the observed lipid changes,” should be removed because it ignores the implications of very common lipid-lowering medications. The reviewer also recommended noting that the inverse association between PFHxS and diabetes found in cross-sectional investigations is due largely to the association between diabetes and albuminuria and advanced kidney disease. Another reviewer suggested that EPA further justify not using cholesterol changes in human epidemiology studies as a driver for setting reference doses. A reviewer commented that EPA should acknowledge the likelihood of confounding from other PFAS on associations between PFHxS and cardiometabolic outcomes, The reviewer further commented that epidemiology studies should not be used as the basis for quantitative dose-response assessment or toxicity factor derivation for cardiometabolic (or any other) end point. Lastly, a reviewer declined to comment on this charge question, noting that the topic is outside of his area of expertise. The tiered comments on Charge Question 2f were:

- 28 Tier 1 Recommended Revisions from five panelists (21 comments came from one panelist)
- 10 Tier 2 Suggested Revisions from four panelists (6 comments came from one panelist)
- 1 Tier 3 Future Considerations

#### Tier 1 Recommended Revisions

[underlined: Tier 1 Recommendation 1 of 28]: Panelist recommended: Recommend revising the evidence stream judgment of observational evidence to moderate based on consistent findings in observational studies of increased odds of high cholesterol in adults Clarification provided: During the meeting there was discussion of whether the cholesterol effects should be considered liver effects. If that change is adopted then this comment does not apply here.

[underlined: EPA Response]: After consideration and additional analysis, EPA determined that there is potential for confounding by other PFAS which prevents the evidence base from reaching a conclusion of “Moderate,” and thus the conclusion of slight human evidence is retained in the revised assessment. Section 3.2.6 has been revised to clarify the consideration of confounding. As detailed in EPA responses in Appendix G.2.7, the revised assessment retains the primary analysis of serum lipids and cholesterol in the cardiometabolic effects section as serum lipids, cholesterol and triglycerides are established risk factors for cardiovascular disease (American Heart Association, 2022). New language was added in Sections 3.2.4 and 3.2.6 of the revised assessment to be more explicit about potential linkages between hepatic effects and changes in cholesterol.

[underlined: Tier 1 Recommendation 2 of 28]: Panelist recommended Clinical and public health relevance appear to be conflated with the statement that, ‘the observed changes in serum lipids may not be adverse.” Recommend omitting and/or noting that what appear to be small changes in cholesterol from a clinical perspective can have large effects on a population level, including with regards to increased use of cholesterol lowering drugs

[underlined: EPA Response]: Text was revised to remove this language.

[underlined: Tier 1 Recommendation 3 of 28]: Panelist recommended Reviewing the lipid findings under heart is fine so long as it is understood that the lipid toxicity is not occurring in the heart, The primary reference to the toxicity of the compound under review needs to be to where the toxicity is occurring, and not downstream effects for other organs. For the PFAS including PFHxS, the toxicity includes altered cholesterol (and possibly triglycerides) metabolism in the liver. The triglyceride outcome remains uncertain). It is fine to have duplication if EPA wants it. It is better to be duplicative than to be misleading about liver. (It is also fine to remove cholesterol from consideration in this section and to consider it only in liver. That would avoid duplication). The problem that is not acceptable would be to fail to acknowledge hepatoxicity because of consideration of downstream effects of the metabolic disruption in the liver.

[underlined: EPA Response]: As previously described, EPA reconsidered organizing cholesterol primarily as a hepatic related outcome. However, cholesterol (and triglycerides) is also pertinent to cardiovascular health. According to the American Heart Association elevated levels of serum cholesterol and triglycerides is a well-established risk factor for atherosclerosis; a cardiovascular disease characterized by the formation and growth atherosclerotic plaques (fatty deposits) that are mostly composed of cholesterol (Fruchart et al., 2004; American Heart Association, 2022). As outlined in the IRIS PFAS Systematic Review protocol and retained in the revised PFHxS assessment, serum lipid findings are primarily discussed as part of characterizing cardiometabolic effects, while noting the importance of these outcomes in the section characterizing hepatic effects. The lipid findings are explicitly considered in drawing the hepatic evidence synthesis conclusions as an indication of potential coherence across biologically related outcomes. This approach of having the primary discussion of lipid effects appear as part of cardiometabolic outcomes makes the PFHxS assessment consistent with other recent IRIS assessments, including of other PFAS.

[underlined: Tier 1 Recommendation 4 of 28]: Panelist recommended Add the following studies under lipids discussion: Aker, A., et al., Cardiometabolic health and per and polyfluoroalkyl substances in an Inuit population. Environ Int, 2023. 181: p. 108283. AND Kang, H., et al., Per- and Polyfluoroalkyl Substances (PFAS) and Lipid Trajectories in Women 45–56 Years of Age: The Study of Women’s Health Across the Nation. Environ Health Perspect, 2023. 131(8): p. 87004.

[underlined: EPA Response]: The recommended studies were added to Appendix Table B-5. However, per the methods described in Section B.3., the studies were not integrated into the main assessment text because they were not considered impactful to existing hazard or toxicity value conclusions. The new studies do not address key uncertainties (e.g., confounding by other PFAS) in the evidence synthesis.

[underlined: Tier 1 Recommendation 5 of 28]: Panelist recommended If there is actual evidence for reverse causation – or any bias of concern, cite it and be specific about what it says. If that means underestimation bias because of fish as a PFHxS source, be clear about it.

[underlined: EPA Response]: A specific source of reverse causation is not being suggested. The text was revised to state that the lack of consistent associations in studies with prospective exposure measurement reduces certainty in the evidence for this effect since these studies reduce the likelihood of reverse causality and other sources of bias compared to cross-sectional studies.

##### Panel Member Recommended Revisions on Hazard Synthesis:

[underlined: Tier 1 Recommendation 6 of 28]: Panelist recommended Please rethink language that appears to be dismissing deleterious effects of PFHxS on cholesterol metabolism. It is not consistent with what is actually in the literature and ignores relevant studies.

[underlined: Tier 1 Recommendation 7 of 28]: Panelist recommended This statement on p. 289/459 should be omitted or revised to say something more general, such as residual confounding is rarely ruled out in a single study but no such source in diet other than PFAS exposure has been found for PFAS in general (nor PFHxS specifically).

[underlined: Tier 1 Recommendation 8 of 28]: Panelist recommended Delete the sentence on p. 289/459 or revise it so that it is clear that food sources and food packaging contain potential sources of exposure which could lead to either under- or overestimation bias.

[underlined: Tier 1 Recommendation 9 of 28]: Panelist recommended If this topic is retained, then it is a responsibility to be explicit about the relationship. My perspective for long half-life PFAS in general and PFHxS specifically is that no article so far provides strong support, and many refute that confounding by diet is the important contributing cause of reasonably consistent PFAS-cholesterol relationships. (And EPA should state its perspective as clearly as possible.)

[underlined: Tier 1 Recommendation 10 of 28]: Panelist recommended Regarding sentence at p. 289/459: “Additionally, a possible explanation for the observed associations is the presence of residual confounding. It is plausible that an association between PFAS exposure and consumption of high cholesterol foods, as suggested in some studies (Susmann et al., 2019; Schaider et al., 2017), could induce a positive association with serum lipids” revisions to the statements quoted includes consideration of what is stated in the quoted articles, and clarity that no such source has been found (and can rarely be ruled out in a general way).

[underlined: EPA Response]: Text was revised to remove this language.

[underlined: Tier 1 Recommendation 11 of 28]: Panelist recommended regarding text from p. 299/459 “Overall, there is some evidence of an association between PFHxS exposure and serum lipids. However, the evidence for other cardiovascular-related effects is mostly null, which raises questions about the adversity of the observed lipids changes. “This statement is understood as partly reasonable in one sense, there is reasonable evidence (more than has been cited by EPA) for a PFHxS association to higher cholesterol. However, a part of the statement is indefensible. The lipid changes are adverse, lead to more people with higher than threshold cholesterol, (and therefore a likelihood of more people taking medication.) This statement as written ignores or dismisses consequential outcomes of the association. It should add all citations of interest (see elsewhere in this document) and it should not dismiss the consequences of association.

[underlined: EPA Response]: Text was revised to avoid implying that lipid changes were not adverse and state that they may be related to PFHxS-induced changes in hepatic functions. However, inconsistent findings across studies and unclear biological significance of decreased serum lipids reduces confidence in the available animal studies, and recent in vivo studies using animal models for cardiovascular disease suggest that in addition to disruption of hepatic lipid production/metabolism PFAS-induced increases in serum levels of cholesterol and triglycerides may also be due to alterations in enterohepatic circulation (Roth et al., 2024). Areas of uncertainty for the available epidemiological studies include potential residual confounding across. The evidence is currently insufficient to infer such a mechanistic conclusion with reasonable certainty.

[underlined: Tier 1 Recommendation 12 of 28]: Panelist recommended “Regarding text on p. 321/459 “The available evidence on PFHxS-induced cardiometabolic effects in humans is considered slight (see Table 3-36). There is some evidence of an association between PFHxS exposure and cardiometabolic effects in humans, specifically an indication of higher serum cholesterol levels. A similar association has been noted for some other long-chain PFAS, including PFOA and PFOS (U.S. EPA, 2016a, b). However, there is little evidence of an association between PFHxS exposure and cardiovascular disease…” This statement is partially true but mostly insupportable. First, EPA will have an easier time thinking about cholesterol if it pins the metabolic disruption to its point of origin, the liver and not the heart. Second, for heart, this dismissal of consequence has two problems. Taking lipid lowering medications has consequences and should be acknowledged. High cholesterol and high LDL cholesterol are ICD-9 codable diagnoses, and need to be followed by clinicians where they exist. And any statement about cardiovascular morbidity and mortality should be accompanied by a statement about the modifying effect of very successful lipid lowering agents and the impact that has on study design, population size, and the difficulty of detecting cardiovascular morbidity and mortality in the era of successful cholesterol-lowering agents. One should not dismiss the clinical and personal significance of its treatment, and one should not dismiss the clinical and personal significance of an environmental stressor that raises the risk of high cholesterol, and all the issues that go with its treatment.”

[underlined: EPA Response]: See above (Tier 1 response for charge questions 2d on hepatic effects and serum lipids) for an explanation on why the primary analysis of lipid is in the cardiometabolic section. Briefly, serum cholesterol and lipids are pertinent to cardiovascular health as they are well-established risk factor for atherosclerosis and stroke (Fruchart et al., 2004; American Heart Association, 2022). However, this evidence is also considered by EPA in the evidence synthesis for hepatic effects as an indication of coherence with biologically related outcomes. This has been clarified in the revised assessment. The cholesterol findings are now discussed as a factor that considered in possibly increasing certainty in the hepatic conclusion. However, as described in Section 3.2.6, due to significant concerns that confounding by other PFAS such as PFOA and PFNA is a substantial possibility, there is still uncertainty in interpreting the strength of evidence. Thus, the synthesis judgment for human evidence remains slight. EPA added text that increasing serum lipids can result in additional people taking cholesterol lower medications.

[underlined: Tier 1 Recommendation 13 of 28]: Panelist recommended: “Regarding text on p. 322/459: “It is possible that cholesterol is a more sensitive measure to PFHxS exposure and that the exposure levels and contrast were inadequate to detect differences in disease risk. However, without additional evidence, the lack of coherence across outcomes reduces confidence in the evidence of the association with cardiovascular effects and indicates that the observed changes in serum lipids may not be adverse.” Tier 1 revision: The good part of this statement is that it does a better job acknowledging lipid changes due to PFHxS. However, the backwards logic of this statement concerning adversity is indefensible. EPA should remove all statements or implications that higher total and higher LDL including higher more abnormal values is not adverse. EPA should stop atomizing liver evidence into multiple organs, which misses the coherence (an important part of Hill criteria).”

[underlined: EPA Response]: Text was revised to clarify the discussion of adversity. Specifically, text was added to the summary of cardiovascular effects to state that an association of PFHxS with serum lipids without an accompanying increase in disease should not be considered inconsequential given, for example, that it will likely lead to more people taking cholesterol lowering medication. Further, as stated elsewhere, serum lipids are metabolized in the liver and thus it is possible that these changes may be supportive of hepatic rather than cardiovascular effects. These nuances are discussed in the revised assessment.

[underlined: Tier 1 Recommendation 15 of 28]: Panelist recommended Regarding Table p. 323/459 Human cholesterol. “Majority of studies in adults report higher serum cholesterol with higher PFHxS exposure, including 40%–60% increases in the odds of high cholesterol. “Yes This is correct. Tier 1: It is what should be emphasized, and it is in EPA’s interest to thoroughly review the literature in a paragraph, with updates that have been provided earlier in this document concerning PFHxS and cholesterol. This is a clinical public health outcome with public health significance.

[underlined: EPA Response]: Text was revised accordingly based on this reviewer’s prior comments.

##### Panel Member Recommended Revisions on interpretation of serum lipids and liver effects:

[underlined: Tier 1 Recommendation 14 of 28]: Panelist recommended The metabolic effects that occur in liver should be evaluated in liver.

[underlined: Tier 1 Recommendation 16 of 28]: Panelist recommended The site of lipid metabolism is liver. If EPA moves lipid metabolism from the heart and brain, where it mostly does not occur, to the liver where it mostly does occur, it can begin to avoid its unacceptable dismissal or downgrading of lipid data. Although emerging studies are suggesting more cardiovascular morbidity and mortality, the reviewer concurs those outcomes are uncertain. However, that is not a reason to imagine that the absence of such data presents a new limitation in the lipid data.

[underlined: EPA Response]: See above (Tier 1 for charge question G.2.7 on hepatic effects)

[underlined: Tier 1 Recommendation 17 of 28]: Panelist recommended: In addition, please update the lipid review as suggested and put it in the correct place, as part of a cohesive body of evidence concerning hepatotoxicity.

[underlined: EPA Response]: See above (Tier 1 responses for charge question G.2.7 on hepatic effects and serum lipids) for an explanation on why the primary analysis of serum lipids is in the cardiometabolic section but also considered in the evidence synthesis for hepatic effects as a possible indication of coherence across biologically related outcomes. c

[underlined: Tier 1 Recommendation 18 of 28]: Panelist recommended: Add study to diabetes section: Park, S.K., et al., Per- and polyfluoroalkyl substances and incident diabetes in midlife women: the Study of Women’s Health Across the Nation (SWAN). Diabetologia, 2022. 65(7): p. 1157–1168.

[underlined: EPA Response]: The recommended studies were added to Appendix Table B-5. However, per the methods described in Section B.3., the studies were not integrated into the main assessment text because they were not identified as impactful to the existing hazard or toxicity value conclusions. Briefly, Park et al. (2022) reported a positive association with incident diabetes but not monotonic across tertiles existing. New studies are primarily null, and would not change the current draft.

[underlined: Tier 1 Recommendation 19 of 28]: Panelist recommended: regarding text at (p. 299/459) “Metabolic changes related to diabetes (e.g., impairments of renal function) may affect the amount of PFHxS measured in blood” It should be clearer, and it should be consistently recalled when studies provide puzzling conclusions that are in fact likely explained by the observation. An EPA colleague has inquired about this recommendation using this language, which is excellent.

[underlined: EPA Response]: Text revised to explicitly acknowledge the potential for reverse causation to explain inconsistent results.

##### Panel Member Recommended Revisions on diabetes and inverse association with PFHxS in (Conway et al., 2016):

[underlined: Tier 1 Recommendation 20 of 28]: Panelist recommended Regarding text on p. 300/459 On the other hand, there was an inverse association with PFHxS exposure in Conway et al. (2016) with higher exposure associated with lower odds of diabetes.

Omit or revise this sentence. It ignores the evidence that EPA just presented. If one looks carefully at the citation, the data represent wholly or mostly reverse causation.

[underlined: Tier 1 Recommendation 21 of 28]: Panelist recommended Regarding text at p. 300/459 “Overall, the evidence for the association between PFHxS exposure and diabetes is mixed. There is some indication of higher odds of diabetes in three studies, one medium and two low confidences, but other studies of similar confidence and design reported null or inverse findings” This statement is mostly fair for its main point but needs to be rewritten for supporting references and for understanding. Again, the inverse association in the Conway et al study is real but the meaning is likely more about excretion mechanics as noted above. The explanation in whole or large part is kidney disease associated with diabetes and associated PFAS excretion (failure of kidney to reabsorb). In a later study by Conway, the relationship to eGFR is noted [Conway et al., 2018].

[underlined: EPA Response]: Text revised to explicitly acknowledge the potential for reverse causation to explain inconsistent results.

[underlined: Tier 1 Recommendation 22 of 28]: Panelist recommended commented that, as PFAS toxicity is primarily occurring in lipids in the liver, metabolic effects that occur in the liver should be evaluated in the liver section; duplicating findings under the cardiometabolic section would be okay, as long as they are also evaluated under the primary organ where toxicity is occurring (Tier 1).

[underlined: EPA Response]: Text was revised to explicitly discuss potential linkages between related outcomes such as metabolic changes to hepatic effects. See responses above (G.2.7. responses to Tier 1 panel member recommended revisions on related topics)

[underlined: Tier 1 Recommendation 23 of 28]: Panelist recommended: Further, reviewer noted that it is always possible to think that bias or confounding could exist, but thought EPA overemphasized the potential for reverse causation or confounding from diet.

[underlined: EPA Response]: Text was revised to reduce emphasis on reverse causation or potential confounding from diet.

[underlined: Tier 1 Recommendation 24 of 28]: Panelist recommended to request that USEPA further justify their non-use of cholesterol changes in the human epidemiology studies as a potential driver for setting reference doses. This would include approximately half of a page further discussing the percentage increase in cholesterol levels, linking that with biological significance for such changes from supportive human clinical studies and further supporting the contribution of other PFAS compounds present that maybe confounding these observations as well co-impacting (see examples done for the studies in the Supplemental Information Appendixes). In this response USEPA needs to acknowledge some of the important considerations across organs as is discussed in the pre-meeting comments from A. Ducatman that emphasizes the importance of looking systemically across organ systems such as liver with other endpoints in order to either strengthen the observations or to be able to biochemically argue against mechanistic support for or not for this biomarker endpoint.

[underlined: EPA Response]: Additional text has been added to describe the concern for confounding by other PFAS, which was considered enough of a concern to keep the evidence synthesis judgment for this outcome based on the epidemiology studies at “slight.,” and the WOE conclusion overall at “evidence suggests.” Typically, dose-response modeling is not performed on health effects with “slight” evidence synthesis or “evidence suggests” integration judgments.

[underlined: Tier 1 Recommendation 25 of 28]: Panelist recommended Consideration has been given to important study attributes for cardiometabolic effects, and the consideration ratings appear overall consistent with (i.e., provide the scientific justification needed for) the overall study confidence level ratings in the draft assessment (e.g., Figures 3-65, 3-66, 3-67, 3-68, 3-69, 3-70, 3-71, 3-72, 3-73 and 3-74). The overall presentation of study results appears clear and various strengths and limitations are described. For example, in regard to epidemiological study limitations for serum lipids, the draft indicates that in studies with stronger associations, there were similar associations with other PFAS (e.g., PFOS, PFOA, and PFNA) that were moderately positively correlated with PFHxS, and so potential confounding across PFAS is not possible to rule out (p. 3–252, lines 34–37). To be more transparent, it seems EPA should acknowledge that such confounding is likely.

[underlined: EPA Response]: Additional text on confounding across PFAS has been added for serum lipids.

[underlined: Tier 1 Recommendation 26 of 28]: Panelist recommended Confounding of the effect of PFHxS exposure by other PFAS seems a certainty in the Grandjean et al. studies, and these studies are deficient under EPA guidelines because the potential for bias to explain some of the results is high based on an inability to rule out residual confounding by key confounders of the exposure-outcome relationship (e.g., see p. 4–21 of the IRIS Handbook; USEPA 2022) since as stated by Grandjean et al. themselves: (1) “Owing to the intercorrelations between the serum PFAS concentrations, further analysis of the possible role of individual PFASs was not pursued, and the observed associations may reflect the effects of the PFAS mixtures” (Grandjean et al. 2017a); (2) “The close correlations prevented meaningful adjustment for concomitant PFAS exposures” (Grandjean et al. 2017b); and (3) “An important weakness of epidemiological studies is the mixed exposures” and more than one PFAS may contribute to the lowering of antibody responses (Budtz-Jorgensen and Grandjean 2018). As an important example discussed in later comments, adjusting for only two confounding PFAS co-exposures (PFOS, PFOA) causes PFHXS to no longer be a statistically significant predictor of critical effects in key analyses of the draft assessment. Thus, epidemiology studies should not be used as the basis for quantitative dose-response assessment and/or toxicity factor derivation based on this or another endpoint (Tier 1 necessary revision). As discussed above, this would not only be consistent with the IRIS Handbook (USEPA 2022), but also more consistent with fairly recent conclusions by the Australian government (FSANZ 2021) and the U.S. Agency for Toxic Substances and Disease Registry (ATSDR 2021).

[underlined: EPA Response]: See previous comments on use of epidemiology studies for toxicity value derivation and the general approach to mixture methods (3 of 5 Tier 1 Charge 1a) and the specific quantitative impact of adjustment for other PFAS on the immune POD (5 of 6 Tier 1 Charge 3a). To summarize, while there is uncertainty in quantitative estimates for a specific PFAS, as acknowledged by Grandjean and co-authors, the BMDL on the association with PFHxS was the same regardless of whether a single-PFAS or multi-PFAS model was used, providing strong support that confounding by other PFAS was not a substantial source of bias for PFHxS. PFAS other than PFOS and PFOA are also not expected to result in substantial confounding given the lower correlations with PFHxS.

Regarding PFAS assessments by other agencies, EPA cannot comment on ATSDR’s decisions regarding the extensive epidemiologic evidence for PFHxS and its utility in their toxicity value derivations. Discussing and comparing decisions across different agencies with different decision contexts, mandates, and guidelines is outside the scope of an IRIS assessment. However, it is important to note that EPA is not alone in using epidemiology data for PFAS toxicity value derivation. Other agencies, including the European Food Safety Authority (EFSA) and California EPA (CalEPA), have used a similar approach.

[underlined: Tier 1 Recommendation 27 of 28]: Panelist recommended: Regarding the points raised by the panel discussion on whether lipid alterations should be discussed as cardiometabolic or hepatic effects could be addressed by moving most of this discussion to the hepatic section (given their synthesis and metabolism in the liver), but keeping relevant text in the cardiometabolic section related to cardiovascular risk factors beginning on page 3-257 (e.g., mostly hypertension and preeclampsia)

[underlined: EPA Response]: See above (Tier 1 response for charge questions 2d on hepatic effects and serum lipids). Briefly, the liver chapter was updated to include a section on lipid and cholesterol accumulation in the liver. Serum lipids and cholesterol are discussed in the cardiovascular section as they are considered risk factors for cardiovascular diseases (specifically atherosclerosis and stroke) (Fruchart et al., 2004; American Heart Association, 2022). The revised liver section summarizes and considers the serum lipids findings, and refers the reader to the cardiometabolic section.

[underlined: Tier 1 Recommendation 28 of 28]: Panelist recommended “Recommend revising the evidence stream judgement of observational evidence to moderate based on consistent findings in observational studies of increased odds of high cholesterol in adults.”

[underlined: EPA Response]: The section was revised to expand the discussion of potential confounding by other PFAS in the association between PFHxS exposure and cholesterol. This additional discussion makes clear that potential confounding is a substantial source of uncertainty that prevents reaching a moderate evidence stream judgment. Therefore, the judgment of slight human evidence is retained in the revised assessment.

#### Tier 2 Suggested Revisions

[underlined: Tier 2 Suggested revisions 1 of 10]: Panel Member Suggested Revision: Recommend noting the potential for negative bias on diabetes outcomes from increased PFAS excretion due to kidney disease.

[underlined: EPA Response]: Text was added to the synthesis of diabetes to reflect this possibility.

[underlined: Tier 2 Suggested revisions 2 of 10]: Panel Member Suggested Revision If cholesterol is also (not solely, that is unacceptable) discussed under heart, ApoB outcomes are reported for PFHxS and could be added As with cholesterol, these belong under liver and could optionally be further discussed under heart. Existing literature on this topic could be added.

[underlined: EPA Response]: EPA reviewed the literature and found that three studies report associations between PFHxS exposure and ApoB. Two of these are included in the synthesis of serum lipids (Averina et al. 2021 and Liu et al., 2020), while the third has been added to Table B-5, Appendix B (Chen et al., 2024) of the revised assessment. This newer study was not interpreted to impact the EPA judgments given that the other two of these studies report null findings for ApoB.

[underlined: Tier 2 Suggested revisions 3 of 10]: Panel Member Suggested Revision There have been a lot of papers about PFOA and PFOS (PFOS and PFHxS have similar exposure sources) and the topic of confounding by diet or by physiology. To date, despite a lot of investigation, no such source of confounding has been found and industry papers acknowledge that it was sought it not found for the class in general for several potential considerations. EPA could be clearer about this.

[underlined: EPA Response]: Text was revised to state that the lack of consistent associations in studies with prospective exposure measurement reduces certainty in the evidence for the effect since these studies reduce the likelihood of reverse causality and other sources of bias compared to cross-sectional studies.. A specific source of reverse causation is not proposed.

[underlined: Tier 2 Suggested revisions 4 of 10]: Panel Member Suggested Revision It may help EPA to note both overlooked studies and recent studies including longitudinal studies that find the relationship including with LDL, ALT, GGT. (See the lists provided).

[underlined: EPA Response]: The suggested studies were added to Appendix Table B-5 of the revised assessment. However, per the methods described in Section B.3., the studies were not integrated into the main assessment text because they were not identified as impactful to the hazard or toxicity value conclusions since they do not address the key uncertainty in the available evidence (i.e., the potential for confounding by other PFAS).

[underlined: Tier 2 Suggested revisions 5 of 10]: Panel Member Suggested Revision Other metabolic outcomes such as effects on insulin resistance and diabetes these are lipid, pancreas, and other organs) likely deserve their own section (The only tier two consideration in this analysis).

[underlined: EPA Response]: These outcomes have their own subsections within the Cardiometabolic Effects Section of the assessment.

[underlined: Tier 2 Suggested revisions 6 of 10]: Panel Member Suggested Revision Add study to diabetes section: Zhang, Y., et al., Human serum poly- and perfluoroalkyl substance concentrations and their associations with gestational diabetes mellitus. Environ Pollut, 2023. 317: p. 120833

[underlined: EPA Response]: The suggested study added to Appendix Table B-5. However, per the methods described in Section 1.2.1 in the main document and in Appendix B, the studies were not integrated into the main assessment text because they were not identified as impactful to the hazard or toxicity value conclusions.

[underlined: Tier 2 Suggested revisions 7 of 10]: Panel Member Suggested Revision recommended noting that what may be small changes in cholesterol on a clinical level can have large impacts on a population level

[underlined: EPA Response]: See previous EPA response to comment (Tier 1 response for charge question 2d on hepatic effects and serum lipids)

[underlined: Tier 2 Suggested revisions 8 of 10]: Panel Member Suggested Revision Additionally, this whole section of cardiovascular risk factors would be more appropriate if combined with Metabolic effects that span pages 3-262 to 3-280 (joining diabetes, gestational diabetes, insulin resistance, metabolic syndrome, and adiposity as the other established cardiovascular risk factors).

[underlined: EPA Response]: Outcomes described in the Toxicological Review of PFHxS are organized by organ/systems as described in Sections 5 and 7 of the EPA IRIS PFAS Protocol at https://iris.epa.gov/document/&deid=345065. The cardiometabolic section (Section 3.2.6) is intended to capture all of the outcomes suggested by the reviewer, and they all contribute to the evidence integration. Narrating the same studies and endpoints in different sections introduces repetition. Thus, the assessment has been revised to refer the reader to relevant chapters and sections when effects may inform responses in more than one target organ or system.

[underlined: Tier 2 Suggested revisions 9 of 10]: Panel Member Suggested Revision The term metabolic dysfunctions may be better rephrased to cardiovascular risk factors, which would also be better aligned with the subheading on Page 3-257.

[underlined: EPA Response]: This term was updated to cardiovascular risk factors.

[underlined: Tier 2 Suggested revisions 10 of 10]: Panel Member Suggested Revision Other discussions of the evidence stream in Table 3-36 appear to be appropriate and supported as the text describes. Discussion of the animal studies in this table seem to support the conclusion that “dose-dependent decreases in serum cholesterol and triglycerides are observed in the available rodent studies” however these changes are not sufficient to describe differences with human results and hence the inconsistency with animal studies remains as indeterminate and appropriate as listed. Absence of a comparative table for the available animal studies for this endpoint was strange especially given the text which discusses species differences and differences in dose. Tier 2 Suggested revision is to plot the dose response information from the high confidence animal studies mentioned between pages 3-280 to 3-284 as is done in Figures of the type shown in Figure 3-76.

[underlined: EPA Response]: A figure was added to illustrate the serum cholesterol evidence in animal studies.

#### Tier 3 Future Considerations

[underlined: Tier 3 Future considerations 1 of 1]: Panel member commented: A problem with this document and a problem with trying to assist its science is that the category “Metabolic effects” is too broad. Reviewing requires redundancy, increasing the workload of reviewer and the EPA. Most of what EPA is discussing (that is not about liver) is about thyroid (which has its own section), or about sex hormones and development or reproduction (which get some consideration), or about diabetes and insulin resistance. It is suggested that diabetes and insulin resistance have their own sections in future documents.

[underlined: EPA Response]: As described in EPA responses to previous comments, endpoints can inform potential effects and evidence integration judgments in more than one health effect category. This is the case with metabolic syndrome. The revised assessment has been updated to referred the reader to the relevant sections where the data for these outcomes are primarily discussed and considered when an outcome is used to inform multiple health effect categories.

### G.2.12 Public Comments on Noncancer Hazard Identification: Cardiometabolic Effects

Public Comment [underlined: (AWWA)]: “Evidence suggests, but is not sufficient to infer, that PFHxS causes increases in serum total cholesterol in humans is scientifically justified, but it is not clear that the observed increases are relevant to disease. For all other endpoints, the results are inconsistent. The USEPA (2023a) reported that there were 34 studies that investigated PFHxS and serum lipids: 25 medium confidence and 9 low confidence studies. The 25 medium confidence studies included 7 general population studies in adults; 5 studies of pregnant women, and 13 studies in adolescents and children. Positive associations between PFHxS and cholesterol were seen in cross-sectional studies in adults; in two prospective cohort studies, one study showed an association between PFHxS and cholesterol (Dunder et al. 2022), while the other study did not (Lin et al. 2019). Most studies in children and adolescents did not find associations between PFHxS exposure and cholesterol. The USEPA described the evidence as slight and based on “general consistent findings for total cholesterol in adults. Evidence for other related outcomes and age groups is inconsistent.” There are fewer studies of cardiovascular disease risks than cholesterol and the associations between PFHxS and disease risks were null. There is uncertainty as to whether the association between PFHxS exposure and total cholesterol seen inconsistently in the general population studies is a true causal association. Although epidemiological studies have found associations between PFOA and PFOS exposure and increased total cholesterol, the association may be confounded by physiological determinants (specifically, enterohepatic cycling of bile acids) that influence both PFAS concentrations in the blood and cholesterol levels (EFSA 2020, Andersen et al. 2021). It is likely that enterohepatic cycling of bile acids could also influence PFHxS serum concentrations and cholesterol in the general population studies. PFHxS concentrations in the US population have been lower than PFOA or PFOS concentrations historically and have not shown as steep of a decline as PFOA or PFOS (CDC 2022). The median concentration of 2.10 µg/L (90th percentile, 5.9 µg/L) in 1999–2000 had declined to 1.7 µg/L (90th percentile, 4.8 µg/L) in 2009–2010 (CDC 2022). The concentrations were relatively unchanged during 2003-2010. For the years 2011–2012, the median concentration was 1.27 µg/L (90th percentile, 3.85 µg/L) and in the most recent years for which data are available (2017–2018) the median concentration was 1.10 µg/L (90th percentile 3.70 µg/L) (CDC 2022). Over the past 60 years or more, cholesterol concentrations have declined in the US general population (Carroll et al. 2005; Carroll and Fryar 2020), showing substantial reductions in total cholesterol during the time when long-chain PFAS serum concentrations (PFAS, PFOA, PFHxS) were higher than current levels. Therefore, other factors have been more impactful on shifting cholesterol levels downward. It is unclear whether further decreases in PFHxS concentrations (assuming a causal association exists) would have any effect on the population-level distribution of cholesterol. Furthermore, there is no compelling evidence to date that increased PFHxS concentrations increase the risk of cardiovascular diseases.”

[underlined: EPA Response]: The uncertainties raised in the comment contribute to the judgment of “evidence suggests.” This conclusion is based “on consistent increases in cholesterol in humans, but with limitations in the available epidemiological studies that introduce uncertainty.” Specifically, “unexplained inconsistency among studies with prospective exposure measurement and for all studies of LDL cholesterol and triglycerides” and potential for confounding by other PFAS.

Public Comment (AWWA): The animal evidence for cardiometabolic effects of PFHxS do not provide any support for the relevance of the observed epidemiological associations between PFHxS plasma concentrations and increased cholesterol. To the contrary, as summarized by the USEPA (2023a) in the Toxicological Review (p. 285), the animal studies demonstrate dose-dependent decreases in serum cholesterol and triglycerides in contrast to the increases reported in epidemiological studies. In vitro studies with human cells/tissues over a range of human-relevant concentrations are critically needed to determine whether there is a plausible MOA for PFHxS effects at the plasma concentrations reported in epidemiological studies, and to evaluate the potential for confounding by a common biological process that effects both PFHxS clearance and cholesterol homeostasis.

[underlined: EPA Response]: There are several experimental design aspects with the available animal studies as well as species extrapolation issues that were considered in evidence integration. Please see discussion in Section 3.2.6. These play an important role in determining the level of confidence in the animal studies and are also considered as part of the evidence integration for this hazard.

### G.2.13 External Peer Review Comments on Charge Question 2g (Hematopoietic Effects, Male and Female Reproductive Effects, and Renal Effects)

#### Peer Review Comment Summary

The majority of the reviewers (7 of 9) commented that they agreed with EPA’s conclusions. One reviewer agreed with EPA’s conclusions on hematopoietic effects; however, he commented that EPA may consider separating out the uric acid and eGFR topics and acknowledging the likely underestimation bias due to the inverse association with eGFR and albuminuria. He also provided additional studies for EPA to consider related to this section and noted osteoporosis and bone mineral density as a missing non-cancer health effect. One reviewer commented that the strain of rat may have an impact on observed hematopoietic effects. Lastly, one reviewer declined to comment on charge question 2g, noting that the topic is outside of his area of expertise. The tiered comments on Charge Question 2g were:

- 8 Tier 1 Recommended Revisions from one panelist
- 26 Tier 2 Suggested Revisions from 5 panelists (one panelist had 21 comments)
- 4 Tier 3 Future Considerations from one panelist

#### Tier 1 Recommended Revisions

[underlined: Tier 1 Recommendation 1 of 8]: Panelist recommended: The data in the EPA review actually show reasonable consistency for uric acid outcomes. Further (Hill, 1965) suggests that we think about whether there is any reason to think that PFHxS is different from PFOA where there are reviews, especially as the data suggests it has the same adverse association.

[underlined: EPA Response]: As described in the assessment protocol this toxicological review is focused on PFHxS and a qualitative comparative analysis that considers other PFAS (including a comparison with PFOS) was not performed (U.S. EPA, 2019b). Uric acid findings inform both hepatic and renal effects. The synthesis of uric acid findings is presented in the renal effects section (3.2.10). To avoid repetition in the hepatic effects section (3.2.4), the reader is now referred the renal effects section for the full synthesis in the revised assessment. In the synthesis of human studies, the text was revised to more clearly emphasize the consistency across a majority of studies.

[underlined: Tier 1 Recommendation 2 of 8]: Panelist recommended: data in NHANES overlap but it is not fair to imply that Moon covered the same ground as Conway (2018) or as Jain and Ducatman (2019a). Instead, please acknowledge that Moon provided a new approach reinforcing the likely underestimation bias in the association to uric acid. Noted above the basic issue is due to the inverse association of PFHxS (and other long half-life PFAS) with declines in eGFR (where uric acid tends to increase due to kidney disease and PFAS to decrease due to kidney disease) and especially with albuminuria, since hyperuricemia is most common in kidney disease.

[underlined: EPA Response]: The text states that Moon et al. (2021) used analyses specifically designed to assess reverse causation and that the results indicate that reverse causation was not likely to explain the results. The text has now been revised to state that while Watkins et al. (2013) proposes that reverse causation could result in overestimation, others, including Jain and Ducatman (2019), have hypothesized that it could instead result in underestimation.

##### Comments from same panel member on uric acid and estimated glomerular filtration rate:

[underlined: Tier 1 Recommendation 3 of 8]: Panelist recommended: Separate out the uric acid and eGFR topics.

[underlined: Tier 1 Recommendation 7 of 8]: Panelist recommended: Reviewer agreed with EPA’s conclusions on hematopoietic effects; however, he commented that EPA may consider separating out the uric acid and eGFR topics (Tier 1)

[underlined: EPA Response]: The primary analyses of the estimated glomerular filtration rate (eGFR) and uric acid findings are both presented in the kidney chapter (see 3.2.10). The synthesis was updated to discuss these two outcomes separately. The updated text was also revised to reflect that reverse causation could attenuate associations. As uric acid findings also inform hepatic effects, the evidence integration analysis for liver effects also considers uric acid findings in the updated draft. .

[underlined: Tier 1 Recommendation 4 of 8]: Panelist recommended: Devote a specific paragraph to higher uric acid. (better under liver)

[underlined: EPA Response]: The section was revised to give uric acid a separate paragraph. This is described in the renal effects section, and is also noted in the hepatic section.

[underlined: Tier 1 Recommendation 5 of 8]: Panelist recommended: Devote a specific paragraph to kidney disease. Data for PFHxS are indeed sparse, and that is acknowledged. The topic is important for PFAS.

[underlined: EPA Response]: The human section of the renal chapter was updated to include a discussion on kidney disease.

[underlined: Tier 1 Recommendation 6 of 8]: Panelist recommended If the EPA report is to cite studies that do now show understanding of the reverse causation problem with kidney disease and especially any albuminuria (and such exists in the quoted paragraph), it should be noted that this association is heavily impacted by a reverse causation issue which makes finding positive associations unlikely.

[underlined: EPA Response]: Text was revised to reflect that reverse causation could occur in either direction.

[underlined: Tier 1 Recommendation 8 of 8]: Panelist recommended Reviewer commented that EPA may consider acknowledging the likely underestimation bias due to the inverse association with eGFR and albuminuria.

[underlined: EPA Response]: The potential for underestimation bias was added to the text in Section 3.2.10.

#### Tier 2 Suggested Revisions

[underlined: Tier 2 Suggested revisions 1 of 26]: Panel Member Suggested Revision: The reverse causation discussion on p. 371/459 is mostly good. Tier 2 Suggested revision: it could be more excellent if it noted that for the most part, any reverse causation could (and more likely would) attenuate actual (and likely causal) relationships for uric acid/hyperuricemia outcomes based on the data. While CKD is not the primary cause of hyperuricemia from PFAS (more likely to be liver), the known kinetics and existing data suggest or mean that CKD will feature lower serum PFAS including PFHxS.

[underlined: EPA Response]: Text was revised to reflect that reverse causation could attenuate associations.

[underlined: Tier 2 Suggested revisions 2 of 26]: Panel Member Suggested Revision Refer again to the inverse (and reverse causation) effect of albuminuria on serum PFAS, identified in several studies, the clearest of which is [Jain et al., 2019], which includes a depiction for PFHxS. This is particularly important because the common causes of kidney disease are hypertension and diabetes, and these are both known causes of albuminuria, and the albuminuria is long understood to appear earlier and more severely in more severe disease [Sosenko et al., 2002, Mani et al., 2016], and may even precede diagnosis. (This happens commonly, enough, especially when the underlying cause is diabetes. Proteinuria from diabetes may precede the diabetes diagnosis). For kidney disease and diseases with strong links to kidney disease, this can lead to unappreciated reverse causation for inverse associations as illustrated by the diabetes and kidney findings in [Conway et al., 2016; Conway et al., 2018], which provided relevant and reasonable data but did not identify the reverse causation as the likely most important contributing cause. Another way to look at this same problem is that every study shows that PFAS including PFHxS are positively correlated with serum albumin (and when the kidney leaks albumin, serum PFAS goes down).

[underlined: EPA Response]: Text was added to the discussion of reverse causality in synthesis of human studies to recognize the role of albuminuria and its relationship with hypertension and diabetes.

[underlined: Tier 2 Suggested revisions 3 of 26]: Panel Member Suggested Revision Mention the role of albuminuria and low serum albumin on population studies investigating kidney disease outcomes or intimately related topic outcomes which reliably cause kidney disease such as diabetes and hypertension. Mention that stages of eGFR in kidney disease influences serum PFAS, just not in a simple way. (Adjustment will miss the point if kidney disease or diseases that routinely cause kidney disease are a part of the investigation question.)

[underlined: EPA Response]: Text was added to the synthesis of renal effects to mention the role of albumin and the stages of GFR.

[underlined: Tier 2 Suggested revisions 4 of 26]: Panel Member Suggested Revision Consider clarifying that the analysis by Moon (2021) indicates that bias due to eGFR is not likely, from the author’s findings/perspective, to explain all of the potentially causal relationship of PFAS to kidney disease in context of PFAS in general.

[underlined: EPA Response]: The text states that Moon et al. (2021) suggests that reverse causation is not likely.

[underlined: Tier 2 Suggested revisions 5 of 26]: Panel Member Suggested Revision EPA could consider adding a discussion of actual causation based on the articles presented for PFHxS in the Stanifer (2018) paper, additional papers since, and the understanding that those who have actual serious kidney disease or any albuminuria or anemia (also common in kidney disease) will have lower serum PFAS for biomechanical reasons, obscuring relationships to kidney disease.

[underlined: EPA Response]: The assessment describes the limitations in the available data that prevent reaching a causal conclusion. Additional text was added to better capture the uncertainty.

[underlined: Tier 2 Suggested revisions 6 of 26]: Panel Member Suggested Revision add additional references: 86. Zeng, X.W., et al., Perfluoroalkyl Acids in Follicular Fluid and Embryo Quality during IVF: A Prospective IVF Cohort in China. Environ Health Perspect, 2023. 131(2): p. 27002.; Cohen, N.J., et al., Exposure to perfluoroalkyl substances and women’s fertility outcomes in a Singaporean population-based preconception cohort. Sci Total Environ, 2023. 873: p. 162267.; Tan, Y., et al., Association between Perfluoroalkyl and Polyfluoroalkyl Substances and Women’s Infertility, NHANES 2013-2016. Int J Environ Res Public Health, 2022. 19(22).

[underlined: EPA Response]: These studies are included in Appendix Table B-5 (one was added in response to this comment, the other two were already included). Evidence of an association with fecundity and infertility is inconsistent across new studies and was similarly inconsistent across existing studies. The conclusion of indeterminate evidence was judged by EPA to be unaffected by the new studies.

[underlined: Tier 2 Suggested revisions 7 of 26]: Panel Member Suggested Revision The Hammarstrand study [Hammarstrand, et al., 2021], found an association of living in a high PFOS/PFHxS region with the risk of fibroids (Leiomyoma), but associations were not significant.

[underlined: EPA Response]: Text was revised to include fibroids.

[underlined: Tier 2 Suggested revisions 8 of 26]: Panel Member Suggested Revision Ovarian Reserve: A study from Karolinska looked at ovarian cortical tissue and antimullerian hormone as a surrogate marker of ovarian reserve in 145 women undergoing elective C-section. There was no correlation of PFHxS with the biomarker, nor with atretic follicles in ovarian cortical tissues [Bjorvang, et al., 2021].

[underlined: EPA Response]: This study was added to Table B-5. This study (Bjorvang et al., 2021) found no association with PFHxS which adds to the inconsistency across currently available studies. The conclusion of indeterminate evidence was judged by EPA to be unaffected by the new study.

[underlined: Tier 2 Suggested revisions 9 of 26]: Panel Member Suggested Revision Suggested revision for menarche: The obvious potential for early menarche to lower serum PFAS including PFHxS is worth mentioning.

[underlined: EPA Response:] Section 3.2.8. discusses menarche and other outcomes informing potential PFHxS-induced responses in the female reproductive system. The impact of menstruation on PFHxS clearance is discussed in Section 3.1.4. Text was added to the section on timing of pubertal development to acknowledge that early menarche may lower serum PFHxS concentrations.

[underlined: Tier 2 Suggested revisions 10 of 26]: Panel Member Suggested Revision Suggested revision: The prenatal-to-puberty design of the HOME study is valuable for longitudinal design and for plausibility. Maternal PFHxS measured in 2003-2006 pregnancies was associated with subjective and objective measures of puberty [Liu et al., 2020]. The weakness is in-pregnancy measures, a weakness common to almost all maternal-child studies.

[underlined: EPA Response]: This study was added to Table B-5. When considered in combination with the other new studies of adiposity, the majority were null and thus would not change the hazard conclusion. EPA notes that timing of pubertal development was considered only as a covariate in this analysis.

[underlined: Tier 2 Suggested revisions 11 of 26]: Panel Member Suggested Revision It is an option to again mention the topic of menstruation/menopause affecting serum PFAS. The potential is obvious, shown by [Jain et al., 2022] and formally discussed in [Ruark et al., 2017], females have lower serum PFAS for several reasons from menarche to after menopause (After because of the long half-life is inferred). In addition, the confounding topic of hysterectomy could be mentioned. Useful reference. PFHxS was associated with menopause in NHANES data [Taylor et al., 2013]

[underlined: EPA Response]: Text in the menopause synthesis was edited to reflect the possibility of reverse causation, citing Jain and Ducatman (2022) and Ruark et al. (2017) as support. Taylor et al. (2013) was added to Table B-5. While it provides some additional support of an association with earlier menopause, EPA judged that the uncertainty related to reverse causation in both available studies prevent these studies from impacting (e.g., strengthening) this conclusion

[underlined: Tier 2 Suggested revisions 12 of 26]: Panel Member Suggested Revision p. 346/359 Minor Suggested Tier 2 revision: Histopathology (of female reproductive organs) should probably say Noncancer Histopathology (of female reproductive organs), just for clarity.

[underlined: EPA Response]: Noncancer health effects and Carcinogenicity are discussed in Sections 3.2 and 3.3, respectively. Female reproductive effects are discussed under noncancer health effects Section 3.2.8. therefore, EPA does not think revising the histopathology subchapter under female reproductive effects as suggested is needed.

[underlined: Tier 2 Suggested revisions 13 of 26]: Panel Member Suggested Revision Change title to Semen and Sperm parameters,

[underlined: EPA Response]: Section title was updated.

[underlined: Tier 2 Suggested revisions 14 of 26]: Panel Member Suggested Revision EPA has chosen not to discuss sperm findings. The rationale presented includes that methods of different studies are different. Tier 2 suggested revision: What was found by different methods, are the methods inadequate to deserve dismissal, and are there associations, or not? Furthermore, sperm count is a measure that is relatively more simple, and widely clinically implemented for specific indications (useful clinical test in a specific context). Article such as Luo et al 2022 (available April 2022) showed a negative association of PFHxS to sperm count, a finding that pertains to more than one PFAS in this and other studies

[underlined: EPA Response]: Sperm findings were considered as part of the review in Section 3.2.9. While one study found decreased normal morphology and concentration, results were inconsistent across five studies and the overall synthesis conclusion was indeterminate evidence.

[underlined: Tier 2 Suggested revisions 15 of 26]: Panel Member Suggested Revision add missing semen/sperm articles Calvert contains PFHxS citations that are not considered in the IRIS review [Calvert et al., 2021] and please note others such as Luo et al. (2022

[underlined: EPA Response]: Luo et al. (2022) is included in Appendix Table B-5. The references from the systematic review by Calvert et al. were also reviewed to determine if additional references were missed. All were included in either the synthesis or Appendix Table B-5. The newly identified studies of semen parameters found no association with PFHxS exposure and thus EPA judged they were not impactful to the assessment conclusions.

[underlined: Tier 2 Suggested revisions 16 of 26]: Panel Member Suggested Revision There is a sense that the sperm data are more important than portrayed, including sperm count. Sperm counts are useful clinical markers in specific settings, and not that complex. Sperm motility is also a test at fertility clinics. Are these clinically useful tests truly as unstandardized as implied? In contrast, The sex hormone data appear to be enough to make a statement that the evidence of association is unsupportive. Overall, the reviewer is simply asking if the science in the EPA document is best served by such a blanket dismissal of the topic.

[underlined: EPA Response]: The intent was not to imply that semen parameters are not important outcomes. The text was revised for clarity.

[underlined: Tier 2 Suggested revisions 17 of 26]: Panel Member Suggested Revision Missing topics from noncancer health effects: influence on breast feeding.

[underlined: EPA Response]: Breastfeeding duration has been added in the revised assessment (Section 3.2.8).

[underlined: Tier 2 Suggested revisions 18 of 26]: Panel Member Suggested Revision This reviewer in general agreed with the USEPA determinations that they had suggestive evidence that PFHxS causes renal toxicity however dose response and consistency with animal studies was indeterminate. In this section on renal effects there was not a mechanistic or supplemental discussion and hence systems-based changes between hepatic and renal toxicities were unable to be discussed. Please see systems-based comments provided as pre- meeting comments that discuss some of the importance of integrating the assessment of toxicity in both organs to support endpoint evaluations. Please note the pre-meeting comments from A. Ducatman regarding uric acid pathways.

[underlined: EPA Response]: Mechanistic studies aimed at evaluating potential cellular/molecular pathway alterations in the renal system after PFHxS exposure were not identified in the literature search and therefore a mechanistic or supplemental discussion was not included in the document.

[underlined: Tier 2 Suggested revisions 19 of 26]: Panel Member Suggested Revision The Agency identified 3 relevant animal studies that evaluated the relationship between PFHxS exposure and hematopoietic effects. Hematocrit was significantly reduced at 28 days in the 3M study. This effect was not observed after 14- or 28-days recovery although this does not seem relevant to the human situation since the half-life of PFHxS is so long. This reduction was also observed at 44 days in the Butenhoff multigenerational study but not at 29 days in the NTP study. Hemoglobin was also reduced at 28 days in males but not females (3M) and at 44 days in males in the Butenhoff study. The NTP study observed no relationship with PFHxS treatment in males or females on day 29. Red blood cells were significantly reduced at 28 days in males and females (3M) and in males at 44 days in the Butenhoff multigenerational study. NTP found no such effect. It is interesting that 2 separate studies identified effects, but not NTP. It may be reasonable to consider the strain of rat NTP is using.

[underlined: EPA Response]: The NTP 2018, and Butternhoff 2009 studies used Sprague-Dawley rats for either 28 or 42 days, respectively. 3M used Charles River rats in their study. 3M reported hemoglobin decreases in males only and the NTP study did not observe alterations in in hemoglobin in male or female animals. The lack of results observed by NTP may be due to insufficient duration or another variable that is not readily discernable. Text has been added to the draft to describe these points.

[underlined: Tier 2 Suggested revisions 20 of 26]: Panel Member Suggested Revision Regarding nomenclature, it should be noted that there is a move to generally use the term kidney in all scientific writing, instead of renal, to focus on more patient-friendly language.

[underlined: EPA Response]: Section 3.2.10 is titled Renal Effects to maintain consistency with published PFAS toxicological reviews.

[underlined: Tier 2 Suggested revisions 21 of 26]: Panel Member Suggested Revision Recommend what type of confounding was of concern for the observational hematopoietic study.

[underlined: EPA Response]: Section 3.2.7 was updated to include a link to the study evaluation for the Jiang et al. (2014) study. This study included a crude (unadjusted) correlation analysis with no consideration of potential confounding by age, gestational week, or any other factors.

[underlined: Tier 2 Suggested revisions 22 of 26]: Panel Member Suggested Revision: Page 3-313, Line 13: Appears to be a reference missing, “9960589@author-year

[underlined: EPA Response]: Reference has been added.

[underlined: Tier 2 Suggested revisions 23 of 26]: Panel Member Suggested Revision: The document could add that a specific problem is the reverse causation issue of protein binding to hemoglobin, which guarantees an association of serum PFAS to hemoglobin and hematocrit (and will therefore attenuate any adverse event relating to hemoglobin or red cell count). Those who have lower hemoglobin of whatever cause, a common finding in disease including kidney disease, will have some degree of lower serum PFAS. (The Lin C.Y. et al study that evaluates hemoglobin and other PFAS also has this problem of not understanding the reverse causation.) Jain, 2020 also shows this. (It is unclear if the author articulated the nature of the association, the paper definitely shows it quite nicely.) The inevitable association of a long-chain PFAS to a protein including albumin and hemoglobin is probably mostly or fully reverse causation, although the possibility of some causation cannot be ruled out or endorsed.

[underlined: EPA Response]: The assessment does not include a synthesis of hematopoietic effects in human studies, because only the evidence base consisted of one uninformative study, so this was not incorporated. EPA notes that this point appears useful to consider in future interpretations of such studies and endpoints in future assessments.

[underlined: Tier 2 Suggested revisions 24 of 26]: Panel Member Suggested Revision: Recommend noting the potential for negative bias on renal outcomes from increased PFAS excretion due to kidney disease.

[underlined: EPA Response]: Section 3.2.10 was updated to include a brief discussion on renal disease resulting in lower PFHxS levels. This could result in the potential for underestimation of the effects of PFHxS exposure.

[underlined: Tier 2 Suggested revisions 25 of 26]: Panel Member Suggested Revision: alteration for uric acid. Move to liver section, It will make more sense and be more valuable.

[underlined: EPA Response]: Uric acid findings inform hepatic and renal effects. The uric acid results are presented in the kidney section (3.2.10). To avoid redundancy the liver section (3.2.4) was updated to refer the audience to the kidney chapter for a detailed discussion. The liver chapter’s evidence integration section also considers uric acid. The updated text was also revised to reflect that reverse causation could attenuate associations. The evidence integration analysis for liver effects also considers uric acid findings in the updated draft.

[underlined: Tier 2 Suggested revisions 26 of 26]: Panel Member Suggested Revision: Reproductive effects --Please note that a cross-reference to pages 3-181 to 3-182 which discusses AGD in the developmental endpoints section would be useful to add to the female reproductive endpoints discussion on pages 3-311 starting at line 8 to 3-312 line 6 and to the male reproductive endpoints discussion on page 3-322 to 3-323.

[underlined: EPA Response]: Language was added to the female and male reproductive effects section referring the reader to the developmental section for the full synthesis.

#### Tier 3 Future Considerations

[underlined: Tier 3 Future considerations 1 of 4]: Panel member commented: In this or future documents, consider clarifying that this source of bias for kidney associated outcomes (again, mostly underestimation bias in kidney disease and the opposite in kidney health) is another important reason to favor longitudinal studies with long follow up, and to place higher value on studies that have entry measures of kidney function including presence/absence of albuminuria. A paper that discusses this and the implications for study design for PFAS in general is Li et al., 2022.

[underlined: EPA Response]: EPA agrees that longitudinal studies with long follow-up are a preferred study design and this is stated in the evidence synthesis section of the PFHxS assessment.

[underlined: Tier 3 Future considerations 2 of 4]: Panel member commented p. 333/459 Paragraph introducing human studies. Tier 3 Optional: This might be a good place to introduce the complicated reverse causation topic that each successful pregnancy (and any subsequent breast-feeding) will decrease serum PFAS. (However, we do not have a good handle on how this would compare to those who are not pregnant and have ongoing menstruation during the same timeframe).

[underlined: EPA Response]: Text was added to the human studies introduction paragraph in Section 3.2.8.to introduce the potential for reverse causation due to differences in excretion introduced by pregnancy, lactation, and menstruation across many of the female reproductive outcomes.

[underlined: Tier 3 Future considerations 3 of 4]: Panel member commented Uterine Fibroids: This topic is not present, and it is a Tier 3 for future long half-life PFAS documents An article led by NIH that appeared in print in May 2023 associated PFHxS with the trajectory of fibroid growth (Hammarstrand et al., 2021). The serum samples were taken between 10–13 weeks of pregnancy, so there is some uncertainty introduced by the intra-pregnancy nature of the exposure measure.

[underlined: EPA Response]: This study was added to Appendix Table B-5. It found a positive but not statistically significant association with total fibroid volume. Existing evidence on gynecological conditions is inconsistent and there is considerable uncertainty due to potential reverse causation. The new study does not inform this uncertainty and thus EPA judged it would not impact the assessment conclusions.

[underlined: Tier 3 Future considerations 4 of 4]: Panel member commented PFHxS was not associated with menarche in [Averina et al., 2023] This paper appeared in November 2023 after review date

[underlined: EPA Response]: This study was added to Appendix Table B-5.

### G.2.14 Public Comments on Hematopoietic Effects, Male and Female Reproductive Effects, and Renal Effects

Public Comment (AWWA): “The evidence for any of these effects from PFHxS is completely inadequate. There were three high confidence studies (3M 2003, Butenhoff et al. 2009, NTP 2018), but the only effects reported were small changes in RBC and platelet parameters that were not consistent across the studies. “

[underlined: EPA Response]: Please see the justifications for each of the judgments drawn by EPA regarding these outcomes in the PFHxS Toxicological Review, which has been revised to address the detailed peer reviewer comments on these topics. EPA notes, as described above in Appendix G.2.13, EPA’s overall judgments on these topics were each supported by the majority of peer reviewers.

Public Comment (NRDC): EPA plans to add review of mammary gland function to the draft during the next revision.

[underlined: EPA Response]: EPA updated the review of mammary gland functions (Section 3.2.8).

## G.3 CHARGE QUESTION 3 AND 4 NONCANCER TOXICITY VALUE DATA SELECTION AND MODELING

3 For PFHxS, no RfC was derived for inhalation exposure. Organ/system-specific RfDs were derived for immune and thyroid effects and considered for use in deriving the oral RfD. The RfD was based on immune effects observed in humans. The study chosen for use in deriving the immune osRfD was Grandjean et al. (2012) with additional analyses by Budtz-Jorgensen and Grandjean (2018), which reported decreased serum anti-tetanus antibody concentrations in children (male and female) at age seven years and PFHxS measured at age five years (see Appendix D and Section 5.2.1). Are the selection of the studies for the immune effects (Butz-Jørgensen and Grandjean, 2018; and Grandjean, 2012) for use in deriving the RfD for PFHxS scientifically justified? Are the modeling approaches appropriate?
  a. If so, please provide an explanation.
  b. If not, please provide an alternative study(ies) or effect(s) that should be used to support the derivation of the lifetime RfD and detail the rationale for use of such an alternative.
  c. As part of the recommendations in “a” or “b” above, please comment on whether the effects selected are appropriate for use in deriving the lifetime RfD, including considerations regarding adversity (or appropriateness in representing an adverse change) and the scientific support for their selection^14^. Please also see charge questions 2b and 2c.
  d. EPA used benchmark dose modeling (BMD) (U.S. EPA, 2012) to identify points-of-departure (PODs) for PFHxS. Are the BMD modeling approaches, selection, and justification of benchmark response levels, and selection of the BMD models used to identify each POD for toxicity value derivation scientifically justified and clearly described?
  e. Given the lack of studies on inhalation exposure to PFHxS, no reference concentration (RfC) is derived. Please comment on this decision.
4 In addition, for PFHxS, an RfD for less-than-lifetime (“subchronic”) exposures is derived in Section 5.2.2. No “subchronic” RfC is derived. The same studies, outcomes, and comparisons were chosen for use in deriving the lifetime and subchronic RfD. Are the selection of these studies and these effects for the derivation of the subchronic RfD for PFHxS scientifically justified?
  a. If so, please provide an explanation .
  b. If not, please provide an alternative study(ies) or effects(s) that should be used to support the derivation of the subchronic RfD and detail the rationale for use of such an alternative.
  c. As part of the recommendations in “a” or “b” above, please comment on whether the effects selected are appropriate for use in deriving the subchronic RfD, including considerations regarding adversity (or appropriateness in representing an adverse change) and the scientific support for their selection.
  d. Given the lack of studies on inhalation exposure to PFHxS, no “subchronic” RfC is derived. Please comment on this decision.

### G.3.1 External Peer Review Comments on Charge Question 3a

#### Peer Review Comment Summary

The majority of reviewers agreed that the derivation of an RfD based on studies for the immune system is scientifically justified and that the modeling approaches are appropriate. One reviewer commented that the raw PFHxS concentration and response data from the studies used for the benchmark dose-response analyses should be provided in the text for transparency. One reviewer commented that because of the extent to which a single study is relied upon for quantitative estimates, it warrants more explicit consideration of correlated PFAS exposures and the refinement of the quantitative relationship through different models. The same reviewer added that, given that there is not an obvious “best” study for deriving the RfD, multiple studies addressing the same endpoint could be used. One reviewer disagreed. Two reviewers declined to comment. The tiered comments on Charge Question 3a were:

- 6 Tier 1 Recommended Revisions from two panelists (one panelist had five comments)
- 2 Tier 2 Suggested Revisions from two panelists
- 3 Tier 3 Future Considerations from two panelists

#### Tier 1 Recommended Revisions

[underlined: Tier 1 Recommendation 1 of 6] Panelist recommended: As discussed in comments under Question 2a, which are also relevant here, the selection of the studies for the immune effects (Butz-Jørgensen and Grandjean, 2018; and Grandjean, 2012) for use in deriving the RfD is not scientifically justified. More briefly, confounding of dose-response for PFHxS by PFAS co-exposures is present in Grandjean et al. studies, which are deficient under EPA guidelines (IRIS Handbook; USEPA 2022). The potential for bias to explain some of the results is high based on an inability to rule out residual confounding by key confounders of the exposure-outcome relationship (e.g., see p. 4-21 of the IRIS Handbook; USEPA 2022) as evidenced most simply by statements by the Grandjean et al. authors themselves. This finding of deficiency for these epidemiology studies is not only consistent with the IRIS Handbook (USEPA 2022), but also more consistent with recent conclusions by the Australian government (FSANZ 2021) and the U.S. Agency for Toxic Substances and Disease Registry (ATSDR 2021). Epidemiology studies should not be used as the basis for quantitative dose-response assessment and/or toxicity factor derivation (Tier 1 necessary revision).

[underlined: EPA Response]: EPA notes that this perspective represents the minority opinion of one panelist. See 3 of 5 Tier 1 Charge 1a for discussion of the use of epidemiology studies for dose-response assessment.

[underlined: Tier 1 Recommendation 6 of 6] Panelist recommended: Alternatively, the assessment should specifically outline why ATSDR, a federal public health agency of the U.S. HSS/CDC charged with protecting communities from the harmful health effects related to exposure to hazardous substances, is wrong about the epidemiology literature being inadequate for use as the basis for toxicity factors (conditional Tier 1 necessary revision).

[underlined: EPA Response]: IRIS assessments are independent analyses of the available evidence that can arrive at different conclusions than those drawn by others. Discussing and comparing decisions across different agencies with different decision contexts, mandates, and guidelines is well outside the scope of an IRIS assessment.

[underlined: The following Panel Member’s comment points to the Public comment from Bruce Allen (for 3M) so both comments are provided and a single EPS response follows]:

[underlined: Tier 1 Recommendation 3 of 6] Panelist recommended: Reviewer brought Dr Bruce Allen’s comments up at page 123-124 and wants EPA to consider these (see Public Comments and EPA Responses in Appendix G.3.10) below. “For very important and influential assessments such as these IRIS PFAS assessments that will ultimately drive remediation efforts across the nation, including the treatment/filtration of drinking water and perhaps even the identification of new drinking water sources, surely the effort to thoroughly evaluate the BMD issues through new independent analyses by EPA or others to know that the results ultimately relied upon are consistent with best practices and fully scientifically defensible (to the extent possible) would be worth it.

[underlined: EPA Response]: EPA thoroughly reviewed and considered the public comments from Bruce Allen (on behalf of 3M). Please see detailed EPA Responses to each point raised by this public comment in Appendix G.3.10

[underlined: Tier 1 Recommendation 4 of 6] Panelist recommended: Panelist commented that epidemiology studies should not be used as the basis for quantitative dose-response assessment and/or toxicity factor derivation because of issues of confounding.

[underlined: EPA Response]: See previous EPA Response on use of epidemiology studies for toxicity value derivation (3 of 5 Tier 1 for Charge 1a).

[underlined: Tier 1 Recommendation 5 of 6] Panelist recommended: EPA should reevaluate the issues raised above (e.g., serum PFHxS is not a significant predictor of antibody concentrations when confounding co-exposures are considered/adjusted for, PFHxS and PFOS/PFOA are not highly correlated as are the examples in Weisskopf et al. 2018) in regard to implications for their draft PFHxS assessment.

[underlined: EPA Response]: This comment concerns the interpretation of the tetanus antibody results related to PFHxS exposures in children aged 5 years. As EPA details in Appendix D.1, the single-PFAS model (just PFHxS) showed a statistically significant slope (p = 0.01) with a lower bound slope of −3.70 ng/mL. Controlling for PFOS and PFOA resulted in a 25% attenuation of the main effect estimate and the loss of statistically significant (p = 0.10) but the same lower bound slope of −3.70 ng/mL. One explanation is that PFOS and/or PFOA was a confounder of the PFHxS effect and controlling for those co-exposures removed confounding. Another possibility is that controlling for co-exposures like PFOS and PFOA actually induced confounding (Weisskopf and Webster, 2017;Weisskopf et al., 2018). The reasons for the change in main effect size for PFHxS are not known. For this reason, there is uncertainty in knowing which point estimate is the best representation of any effect of PFHxS. However, the lower bounds on the point estimates (βLB) are the same for the single-PFAS and multi-PFAS models, minimizing the effect of the potential confounding given the lower bound is ultimately used for point-of-departure derivation. Thus, the BMDL is the same from each of the models. EPA used this BMDL as the POD advanced for toxicity value derivation.

[underlined: Tier 1 Recommendation 6 of 6] Panelist recommended: The raw PFHxS concentration vs. response data from the selected human epidemiological studies that were used to conduct the benchmark dose-response analyses should be provided, similar to the dose-response data from animal studies provided in Tables D-15, D-17, and D-22. This will enable readers to repeat the benchmark dose-response analysis results. It is important to clarify that this comment only refers to the actual PFHxS concentration vs. response data, not the human identifiable information. An example of sharing the actual PFAS concentration vs. response data in a PFAS risk assessment document refer to the 2018 PFAS risk assessment document from European Food Safety Authority (EFSA). Please refer to Appendix B – Benchmark Dose Modeling (Pages 251–260) of this document (EFSA, 2018). It is important to provide these raw PFAS concentration vs. response data because these data are essential in the final recommendation of this risk assessment document. These data will make this risk assessment transparent and strengthen the scientific basis of this risk assessment and will make the results reproducible. These data will also help future studies, in which other researchers may build new dose-response models and evaluate new models with these data to see if results are consistent with this EPA report.

[underlined: EPA Response:] Regarding the data from (Grandjean et al., 2012; Budtz-Jørgensen and Grandjean, 2018a, b), “raw” epidemiology data from individuals typically contains personal identifiers that are confidential and are not shared by investigators for that reason. EPA does not have the individual data that the reviewer references, nor do EPA’s dose-response assessment methods require such details.

#### Tier 2 Suggested Revisions

[underlined: Tier 2 Suggested revisions 1 of 2]: Panel Member Suggested Revision. If possible, the plots showing the benchmark dose-response fitting results should be provided in the Appendix D. This will enable readers to review the goodness-of-fit of the benchmark dose-response analyses.

[underlined: EPA Response]:. As the dose-response relationships used estimate the BMDs and BMDLs were described by the authors of Budtz-Jorgensen and Grandjean (2018), EPA does not possess those plots. EPA did receive details of the regression analyses from those authors which provided information on model and parameter fits. EPA made these requested details available to the public (Budtz-Jørgensen and Grandjean, 2018b).

[underlined: Tier 2 Suggested revisions 2 of 2]: Panel Member Suggested Revision. Because of the degree to which this study [Budtz-Jorgensen 2018] is relied on for quantitative estimates, it warrants more explicit consideration of two issues: (1) the extent to which effects of PFHxS have been fully isolated from the effect of correlated PFAS exposures and (2) the refinement of the quantitative relationship between PFHxS and immunologic impairment through evaluation of different models.

[underlined: EPA Response]: The Budtz-Jorgensen 2018 paper evaluated three different model forms for these data on two different antibody endpoints and for two different pairs of ages of biomarker collection and antibody biomarker collection. In all, there were 24 different combinations of results. EPA selected the best fitting of these three model forms and further evaluated the selected piecewise linear model with a single PFAS (here PFHxS) alongside a model that also controlled for PFOA and PFOS. EPA’s detailed analysis and consideration of these issues is described in Appendix D.

#### Tier 3 Future Considerations

Combined related comments:

[underlined: Tier 3 Future considerations 1 of 3] Panel member commented: Given that there is not an obvious “best” study for deriving the RfD, multiple studies addressing the same endpoint could be used.

[underlined: Tier 3 Future considerations 3 of 3] Consider multiple studies addressing the same endpoint to evaluate the sensitivity of the RfD to the specific study that is used, given that there is not an obvious single “best” study to rely upon. This might involve different studies of immune response but could also be extended to other endpoints of interest, e.g., liver effects.

[underlined: EPA Response]: The RfD is selected based on the study or studies interpreted with the greatest confidence (in the study methods; in the precision of the POD; see IRIS Handbook Chapter 8.4.2) and which is also expected to be protective for all other identified health effects; thus, it is frequently based on the most protective POD. Although combining multiple studies reporting results for the same endpoint may provide additional confidence in the strength or precision of a POD, such combining requires very similar study methods and data, especially for epidemiology studies. For example, for immune effects there were several analyses of PFHxS exposures and antibody concentrations outcomes which might seem similar enough to combine. However, all but one of those analyses (Budtz-Jørgensen and Grandjean, 2018b) used models where both the exposure (PFHxS) and the outcome (antibody concentrations) were log-transformed. Such models can show evidence of dose-response to support a hazard conclusion, but EPA does not have a precedent for using those types of models for deriving benchmark dose results. Untransformed outcome data is preferred because EPA can use those data to derive toxicity values. In this situation, Budtz-Jorgensen and Grandjean (2018) was the most appropriate study since it was the only analysis that allowed for estimation of a POD (because only the outcome variable was log-transformed) and it had the additional benefit of adjustment for other PFAS, which was not available in other studies. In another example, for birthweight deficits, the results of 27 different study were combined using a meta-analysis and the summary effect estimate was used to derive the RfD.

[underlined: Tier 3 Future considerations 2 of 3 Panel Member Future Consideration]: reviewer noted osteoporosis and bone mineral density as a missing non-cancer health effect.

[underlined: EPA Response]: The synthesis of evidence for osteoporosis and bone mineral density was added in the revised assessment (Section 3.2.11).

### G.3.2 External Peer Review Comments on Charge Question 3b

#### Peer Review Comment Summary

The dissenting reviewer from above commented that epidemiology studies should not be used as the basis of a quantitative dose-response assessment (Tier 1). Further, this reviewer commented that the studies used by EPA have too high a potential for residual confounding (Tier 1). They also commented that an animal PFHxS toxicity study should be used as the basis of a dose-response assessment and toxicity factor derivation. Two reviewers declined to comment. The tiered comments on Charge Question 3b were:

- 3 Tier 1 Recommended Revisions from 1 panelist
- 0 Tier 2 Suggested Revisions
- 0 Tier 3 Future Considerations

#### Tier 1 Recommended Revisions

[underlined: Tier 1 Recommendation 1 of 3]: Panelist recommended: A quality animal PFHxS toxicity study(ies) should be used as the basis of dose-response assessment and toxicity factor (e.g., RfD) derivation.

[underlined: EPA Response]: Although the hazard judgment is based primarily on the available animal studies, with support from the human studies, once this judgment is made, the decision shifts to identifying the most appropriate and reliable study for deriving a quantitative estimate protective of all persons. Thus, given the similarities in findings across evidence streams and the availability of well-conducted human studies on the endpoint of interest, EPA considered higher quality epidemiological studies for use in dose-response analysis. As per EPA guidelines and the IRIS Handbook, EPA generally considers evidence from well-conducted studies in humans to be preferable to animal studies. As stated in the Toxicological Review of PFHxS the Grandjean et al. (2017a) and Grandjean et al. (2012) were studies were prioritized for RfD derivation as human studies are typically preferred over animal studies to eliminate interspecies extrapolation uncertainties.

[underlined: Tier 1 Recommendation 2 of 3]: Panelist recommended: The draft assessment currently contains both a chronic and subchronic RfD based on decreased serum total T4 levels in a high quality Wistar rat study (Ramhøj et al. 2018, Table ES-1), which is a good place to start as the basis of a final chronic (or subchronic) RfD.

[underlined: EPA Response]: Chronic and subchronic toxicity values based on thyroid effects in rats are not protective against other health effects and therefore would not be appropriate for moving forward as RfDs. Instead, RfDs derived from developmental immune effects in children were prioritized over the other candidate values since they are protective against all other toxicologically-relevant human health effects. Furthermore, the RfDs from animal data are derived from a combined (both sexes) dataset and may not translate to protective values for either males or females considered separately.

[underlined: Tier 1 Recommendation 3 of 3]: Panelist recommended Because of the extent to which a single study is relied upon for quantitative estimates, it warrants more explicit consideration of correlated PFAS exposures and the refinement of the quantitative relationship through different models.

[underlined: EPA Response]: The Budtz-Jorgensen and Grandjean 2018 paper evaluated three different model forms for these data on two different antibody endpoints and for two different pairs of ages of biomarker collection and antibody biomarker collection. In all, there were 24 different combinations of results. EPA selected the best fitting of these three model forms and further evaluated the selected piecewise linear model with a single PFAS (here PFHxS) alongside a model that also controlled for PFOA and PFOS. EPA’s detailed analysis and consideration of these issues is described in Appendix D.

### G.3.3 External Peer Review Comments on Charge Question 3c

#### Peer Review Comment Summary

Three reviewers that the effects selected are appropriate for use in deriving the lifetime RfD, including the level of adversity of the outcomes. One reviewer commented that the antibody changes used as critical effects by EPA are not appropriate for deriving the lifetime RfD as they are not demonstrably adverse. One reviewer commented that further investigation on the immune effects of PFHxS in older adults would be appropriate. Two reviewers declined to comment. The tiered comments on Charge Question 3c were:

- 3 Tier 1 Recommended Revisions
- 1 Tier 2 Suggested Revisions
- 1 Tier 3 Future Considerations

#### Tier 1 Recommended Revisions

[underlined: Tier 1 Recommendation 1 of 3]: Panelist recommended commented that epidemiology studies should not be used as the basis of a quantitative dose-response assessment, the studies used by EPA have too high a potential for residual confounding, and that an animal PFHxS toxicity study should be used as the basis of a dose-response assessment.

[underlined: EPA Response]: With respect to the use of epidemiology studies, see response to Charge 1a. (Appendix G.1.1), T[underlined: ier 1 Recommendation 3 of 5.] With respect to use of antibody response, this recommendation is not consistent with comments from other peer reviewers on this assessment or peer reviews for other PFAS. While there is some debate regarding the biological significance of small changes in serum antibody levels (Luster et al., 2005; IPCS, 2012; DeWitt et al., 2016; Agarwal and Cunningham-Rundles, 2007), but EPA’s interpretation was supported during the external peer review of the PFOS and PFOA Toxicological Reviews (U.S. EPA, 2022c) as well as by the majority of reviewers of PFDA and this IRIS PFHxS Toxicological Review. Vaccine immune titers are functional measures of adaptive immune response and important indicators of clinically relevant immunotoxicity; reduced antibody production is an indication of immunosuppression and may result in increased susceptibility to infectious diseases generally (i.e., not limited to those specifically studied). EPA defines an “adverse effect” as a “biochemical change, functional impairment, or pathologic lesion that affects the performance of the whole organism or reduces an organism’s ability to respond to an additional environmental challenge” (U.S. EPA, 2002). Reduced antibody titers are thus considered an appropriate effect for the derivation of a candidate RfD.

[underlined: Tier 1 Recommendation 2 of 3]: Panelist recommended The proof (of adversity) is in the scientific pudding, or not (in this case), and all this (e.g., confounding co-exposures and their effects on modeling results, frequent lack of statistical significance for meaningful antibody level changes in epidemiology studies, WOE for no statistically significant effects on disease) brings into serious question the validity of the EPA’s assumptions regarding the existence of truly adverse effects on serum antibodies that are associated with and/or can be confidently attributed specifically to PFHxS. EPA should acknowledge that adversity has not been demonstrated (and that serum PFHxS is not a reliable predictor of antibody changes) and move forward with a different endpoint(s)

[underlined: EPA Response]: See previous EPA responses on adversity of changes in serum antibodies in response to vaccination (1 of 3 Tier 1 Charge 3c).

[underlined: Tier 1 Recommendation 3 of 3]: Panelist recommended Based on such considerations, effects from quality animal toxicity studies of PFHxS are appropriate, scientifically supported and should clearly be preferred for use in RfD derivation (Tier 1 necessary revision), while use of the epidemiology studies currently being utilized should be precluded.

[underlined: EPA Response]: See the response to 3 of 5 Tier 1 Charge 1a. (Appendix G.1.1)

#### Tier 2 Suggested Revisions

[underlined: Tier 2 Suggested revisions 1 of 1]: Panel Member Suggested Revision: the adversity (or the lack thereof) of these purported antibody level effects by PFHxS that should be duly considered.

[underlined: EPA Response]: See previous comment on adversity of changes in serum antibodies in response to vaccination (1 of 3 Tier 1 Charge 3c).

#### Tier 3 Future Considerations

[underlined: Tier 3 Future considerations 1 of 1]: Panel member commented: The developmental immune effects are based on exposure during sensitive developmental life stages. This is appropriate. However, one thing warrants further investigation is the effect on the older adults (i.e., >60 years old) who have been exposure to PFHxS for several decades and who also have reduced immune function compared to young adults. Also, as described on Page 5–13, in the United States, tetanus is a concern primarily among old adults, who may be unvaccinated or inadequately vaccinated and thus are at a relatively higher risk of diseases. This should be discussed if available information is available.

[underlined: EPA Response]: A few studies of immunosuppression in adults are available and discussed in the evidence synthesis (Section 3.2.2, Table 3-12 and associated text).

### G.3.4 External Peer Review Comments on Charge Question 3d

#### Peer Review Comment Summary

Of the reviewers that commented on this question the majority (4 of 5) agreed with EPA’s approach for identifying PODs. One reviewer disagreed with EPA’s approach for identify PODs due to the immunotoxicity endpoints used and the use of ½ of the standard deviation. The reviewer noted that if the endpoints are not changed, he recommends that EPA account for at least two co-exposures (i.e., PFOA and PFOS) in the modeling. One reviewer noted several inconsistencies in Section D.2.1 that should be corrected. The reviewer also commented that additional dose-response analysis tools could be used to supplement the results from EPA’s Benchmark Dose Software. One reviewer commented that Korevaar et al. (2016a) could be used to identify a reduction in serum T4 that could be considered adverse, which could be used in place of the 1 standard deviation recommended when biological information is not sufficient to identify the BMR. Three reviewers declined to comment on question 3d. The tiered comments on Charge Question 3d were:

- 8 Tier 1 Recommended Revisions from two reviewers
- 4 Tier 2 Suggested Revisions from three reviewers
- 0 Tier 3 Future Considerations

#### Tier 1 Recommended Revisions

[underlined: Tier 1 Recommendation 1 of 8]: Panelist recommended accordingly, to help ensure the reliability of BMD modeling for accurate POD estimate(s) for PFHxS, all BMD modeling-related issues should be duly considered and addressed through re-running analyses as needed.

[underlined: EPA Response]: The dose-response analyses included in IRIS assessments undergo quality control analyses and the BMD modeling files are made accessible via HERO in the modeling Appendix D.

[underlined: Tier 1 Recommendation 2 of 8]: Panelist recommended reviewer indicated in oral comments during the teleconference (on 3-1-24), the data used for BMD modeling should be made publicly available as this is required for transparency.

[underlined: EPA Response]: Epidemiological data from individuals typically contains personal identifiers that are confidential and not shared by investigators for that reason. EPA does not have the individual-level data that the reviewer references, nor is it required for dose-response analysis. For animal studies, the data used for BMD modeling is fully available in the tables of Appendix D.2.

[underlined: Tier 1 Recommendation 3 of 8]: The panel member’s comment has been summarized for brevity. The complete recommendation can be found on p. 12–127 of peer review report) regarding BMR of 1/2 SD: This is problematic as it is not adequately supported (e.g., see previous comment that the assay-specific level is 0.01 IU/mL) and internally inconsistent as the draft does not scientifically support the definition of <0.1 IU/mL as the adverse cutoff. These justifications/support for the BMR should be removed.

[underlined: EPA Response]: [underlined: From Appendix D.1:] In the absence of a clear definition of what minimal level of change in a continuous endpoint is biologically significant, a default BMR of 1 SD change from the control mean may be selected, as suggested in EPA’s draft Benchmark Dose Technical Guidance Document (U.S. EPA, 2012). EPA provided details in Appendix D.1 on this point, noting that this decision was supported by the majority of peer reviewers As noted in EPA guidelines, a lower BMR can also be used if it can be justified on a biological and/or statistical basis. Statistically, the technical guidance additionally suggests that studies of developmental effects can support lower BMRs. Biologically, a BMR of ½ SD is a reasonable choice as anti-tetanus antibody concentrations prevent against tetanus, which is a rare, but severe and sometimes fatal infection, with a case-fatality rate in the United States of 13% during 2001–2008 (Liang et al., 2018). The case-fatality rate can be more than 80% for early lifestages cases (Patel and Mehta, 1999). Selgrade (2007) suggests that specific immunotoxic effects observed in children may be broadly indicative of developmental immunosuppression impacting these children’s ability to protect against a range of immune hazards, which has the potential to be a more adverse effect that just a single immuno-toxic effect. Thus, decrements in the ability to maintain effective levels of tetanus antitoxins following immunization may be indicative of wider immunosuppression in these children exposed to PFHxS.

[underlined: Tier 1 Recommendation 4 of 8]: Panelist recommended If EPA chooses to continue to rely on the epidemiological PFAS mixture studies for dose-response assessment, contrary to my recommendations (see previous comments), modeling results that attempt to account for at least two co-exposures (i.e., PFOS and PFOA) should be used (Tables D-2 and D-4)

[underlined: EPA Response]: The modeling results in Table D-2 and D-4 show the same BMDLs for the single-PFAS models and the multi-PFAS models.

[underlined: Tier 1 Recommendation 5 of 8]: Panelist recommended (The panel member’s comment has been summarized here for brevity. The complete recommendation can be found starting on page 127 of the peer review report.) For very important and influential assessments such as these IRIS PFAS assessments that will ultimately drive remediation efforts across the nation, including the treatment/filtration of drinking water and perhaps even the identification of new drinking water sources, surely the effort to thoroughly evaluate the BMD issues through new independent analyses by EPA or others to know that the results ultimately relied upon are consistent with best practices and fully scientifically defensible (to the extent possible) would be worth it.

[underlined: EPA Response]: For every assessment, EPA conducts a systematic literature review and evaluates each study. When hazards are identified, EPA advances higher quality studies of those hazards for potential use in dose-response analyses to derive toxicity values. EPA thoroughly and transparently evaluates the model fits and the estimated BMDs and BMDLs, and documents these and other (e.g., BMR selection) modeling decisions.

[underlined: Tier 1 Recommendation 6 of 8]: Panelist recommended Further investigation on the immune effects of PFHxS in older adults would be appropriate.

[underlined: EPA Response]: EPA notes that this comment is directed towards the research community and not the IRIS Program or this assessment.

[underlined: Tier 1 Recommendation 7 of 8]: Panelist recommended In Section D.2.1., when describing the modeling procedure for dichotomous noncancer data, it is said that for these data, various models available within the software were fit using a BMR of 10% extra risk. However, according to Table 5-4 (Page 5-10), a 5% extra risk was used for the developmental effects. This should be clarified.

[underlined: EPA Response]: Section D.2.1 discusses the modeling procedure that applied to animal endpoints. For these data, the Gamma, Logistic, Log-Logistic, Log-Probit, Multistage, Probit, Weibull, and Dichotomous Hill models available within the software were fit using a benchmark response (BMR) of 10% extra risk. These modeling procedures differ from the procedures used to model human data. The BMR values in Table 5-4 (now Table 5-5) refer to the BMR of the developmental effects for humans, which is 5% as discussed in Section D.1.1.A 5% extra risk is commonly used for dichotomous developmental endpoints as recommended by Benchmark Dose Technical Guidance (U.S. EPA, 2012).

[underlined: Tier 1 Recommendation 8 of 8]: Panelist recommended Also in Section D.2.1., when describing the modeling procedure for continuous noncancer data, it is said that for these data, various models available within the software were fit using a BMR of 1 SD when no toxicological information was available to determine an adverse level of response. However, in Table 5-4 (Page 5-10), a BMR of ½ SD was used for the developmental immune effects. This should be clarified here.

[underlined: EPA Response]: For the continuous immune data, BMRs of 1 SD and ½ SD were used and results were presented.

#### Tier 2 Suggested Revisions

[underlined: Tier 2 Suggested revisions 1 of 4]: Panel Member Suggested Revision public comments also express concerns about a BMR of ½ SD that should be duly considered.

[underlined: EPA Response: From Appendix D.1:] In the absence of a clear definition of what minimal level of change in a continuous endpoint is biologically significant, a default BMR of 1 SD change from the control mean may be selected, as suggested in EPA’s draft Benchmark Dose Technical Guidance Document (U.S. EPA, 2012). A lower BMR can also be used if it can be justified on a biological and/or statistical basis. Statistically, the technical guidance additionally suggests that studies of developmental effects can support lower BMRs. Biologically, a BMR of ½ SD is a reasonable choice as anti-tetanus antibody concentrations prevent against tetanus, which is a rare, but severe and sometimes fatal infection, with a case-fatality rate in the United States of 13% during 2001–2008 (Liang et al., 2018). The case-fatality rate can be more than 80% for early lifestages cases (Patel and Mehta, 1999). Selgrade (2007) suggests that specific immunotoxic effects observed in children may be broadly indicative of developmental immunosuppression impacting these children’s ability to protect against a range of immune hazards, which has the potential to be a more adverse effect that just a single immuno-toxic effect. Developmental immunosuppression is even more adverse than decreased anti-tetanus antibody concentrations in children and further justifies the use of a BMR of ½ SD. This previous sentence has been added to the text in D.1 to clarify this point.

[underlined: Tier 2 Suggested revisions 2 of 4]: Panel member suggested revision for benchmark dose-response analysis, this risk assessment used the EPA’s Benchmark Dose Software (BMDS, Version 3.2). This is good. However, in this field, there are many other dose-response analysis tools, such as PROAST (National Institute for Public Health and the Environment, Netherlands) and the online Bayesian Benchmark Dose Modeling System (BBMD, Indiana University) (Shao and Shapiro, 2018). Some researchers may wonder if the dose-response analysis results will be the same or similar if a different software tool is used. As such, it is recommended that the dose-response analyses be repeated using a different software program (e.g., BBMD), and the results are provided in the Appendix. If the results are similar, this will well address potential challenges related to the choice of the EPA’s BMDS software. One example of this comparison can be found in the study by Chou and Lin (2020). In this study, the authors conducted dose-response analyses of in vitro high-throughput assays, in vivo animal toxicity data, and human epidemiological data using three approaches, including the EPA BMDS software, the Indiana University’s BBMD software, and a new approach developed by the authors. They found that the results were similar.

[underlined: EPA Response]: The EPA acknowledges that different software platforms exist for BMD analysis and is aware that differences in methodology and/or computer code may affect results. However, use of EPA’s BMDS is consistent with the EPA’s current standard of practice and the development of methods to incorporate BMD results across different platforms into chemical risk assessment is beyond the scope of this assessment.

[underlined: Tier 2 Suggested revisions 3 of 4]: Panel Member Suggested Revision Table 5-4 encapsulates the Agency’s rationale for selecting the BMD modeling of PFHxS outcomes. The Agency states that “No information is readily available that allows for determining a minimally biological significant response. The BMD Technical Guidance … recommends a BMR based on 1 SD for continuous endpoints when biological information is not sufficient to identify the BMR.” It would seem that the data of Korevaar et al., (2016a and b: DOI 10.1016/S2213-8587(15)00327-7 and 10.1111/cen.13106) could be used to identify a reduction in serum T4 that could be considered adverse.

[underlined: EPA Response]: The data from the prospective cohort study (Korevaar et al., 2016) suggest that both low and high levels of maternal serum T4 are associated with risk for low IQ; the non-monotonic relationships from this epidemiological data make it difficult to use as the basis to extrapolate risk of developmental immune effects in animal models.

[underlined: Tier 2 Suggested revisions 4 of 4]: Panel Member Suggested Revision The antibody changes used as critical effects by EPA are not appropriate for deriving the lifetime RfD as they are not demonstrably adverse.

[underlined: EPA Response]: See response to (7 and 8 of 10 Tier 1 Charge 2a) (Appendix G.2.1).

### G.3.5 External Peer Review Comments on Charge Question 3e

#### Peer Review Comment Summary

Eight reviewers agreed with EPA that in the absence of data, an RfC cannot be derived. One reviewer commented that derivation of an RfC should be a priority, particularly for PFHxS and other PFAS with occupational exposure. The tiered comments on Charge Question 3e were:

- 0 Tier 1 Recommended Revisions
- 0 Tier 2 Suggested Revisions
- 1 Tier 3 Future Considerations

#### Tier 3 Future Considerations

[underlined: Panel Member Future Consideration] (1 of 1 Tier 3 Charge 3d) Inhalation exposures can be important, particularly for workers in certain industries. Derivation of an RfC should be a priority, particularly for PFHxS and other PFAS with occupational exposures.

[underlined: EPA Response]: EPA acknowledges the utility of an RfC, however the current evidence base lacks the necessary data to inform the derivation of a RfC value for PFHxS.

### G.3.6 External Peer Review Comments on Charge Question 4a

The majority of the panel members (seven of nine) agreed with EPA’s decision to use the same studies to derive the lifetime and subchronic RfD. One panel member declined to comment on charge question 4. The remaining panelist provided two tier one recommendations. The tiered comments on question 4a were:

- 2 Tier 1 comments from one panelist
- 0 Tier 2 comments
- 0 Tier 3 comments

#### Peer Review Comment Summary Tier 1 Recommended Revisions

[underlined: Tier 1 Recommendation 1 of 2]: Panelist recommended: “PFAS co-exposures and statements by the Grandjean et al. authors themselves highlight the inability to rule out residual confounding of the exposure-outcome relationship27, making these studies deficient under EPA guidelines (e.g., see p. 4–21 of the IRIS Handbook; USEPA 2022). Consequently, these epidemiology mixture studies should not be used as the basis for quantitative dose-response assessment and/or toxicity factor derivation.”

[underlined: EPA Response]: The two studies that were used for the Budtz-Jorgensen 2018 analysis Grandjean et al. (2012); Grandjean et al. (2017a) were evaluated for confounding according to the Handbook and judged to be adequate and of medium confidence overall. The hazard identification judgment that the evidence indicates PFHxS exposure is likely to cause immunotoxicity in humans given sufficient exposure conditions is based on generally consistent evidence of reduced antibody response to vaccination at median blood concentrations of 0.2–0.6 ng/mL in children. The direction of association was generally consistent across studies and timing of exposure and outcome measures, although not all the results were statistically significant. A detailed discussion of use of quantitative dose-response assessment for immune effects is included in Section 3.2.2. See also 3 of 5 Tier 1 Charge 1a and 5 of 6 Tier 1 Charge 3a.

An often-voiced concern for use of epidemiologic data specifically in the PFAS assessments, particularly for toxicity value derivation, is the potential for confounding across the PFAS. The general population is exposed to a variety of PFAS and it can be difficult to disentangle the independent effect of a single PFAS. It is important to acknowledge this as a source of uncertainty in the observational epidemiology evidence, but only in conjunction with informative discussions on the likelihood and direction of potential confounding for the specific studies and populations being evaluated. It is not scientifically justified to use a hypothetical concern over possible confounding based on limited direct evidence in epidemiological studies of PFAS as a reason to automatically dismiss all epidemiological studies of PFAS exposure, including large databases of evidence for some health outcomes.

There are standard methods in epidemiology and systematic review to evaluate the potential for confounding within individual studies and across studies. For some PFAS, there are studies in occupational populations or in communities with large water contamination events that are less susceptible to this source of confounding because a single PFAS predominates the exposure. This type of study is largely not available for PFHxS (a contamination event did occur in Ronneby, Sweden, but PFOS was a co-contaminant). Thus, in assessing the potential for confounding by other PFAS, the assessment primarily relied on analysis of results from multipollutant modeling with adjustment for co-exposures through a variety of mixture approaches. While not all of the available studies presented this information, the results in the studies that perform multipollutant modeling can be informative for the body of evidence as a whole. There was also consideration of the correlations between PFAS in the study populations as these correlations vary across populations; where correlations are low, confounding is of lesser concern.

For health outcomes that advanced to the dose-response part of EPA’s systematic review processes, particularly those with consistent results across different epidemiological studies with heterogeneous populations and exposure scenarios, the potential for any confounding by co-occurring PFAS was deemed unlikely to fully explain the identified hazards. This does not eliminate the possibility of confounding existing, and this source of uncertainty is acknowledged in the assessment. However, uncertainty is an inherent part of the risk assessment process. Use of animal data instead of epidemiologic data does not eliminate uncertainty, but rather trades it for a different source (i.e., interspecies extrapolation).

For toxicity value derivation in the PFHxS assessment specifically, the outcome of vaccine response underwent this analysis, and it was determined that confounding was unlikely to explain the observed effects, and further, that adjustment for other PFAS had no impact on the POD (see response for vaccine response for additional detail). In contrast, for other outcomes, such as liver enzymes and serum lipids, the potential for confounding by other PFAS was considered a greater source of uncertainty that prevented the evidence from reaching a judgment of “moderate.”

Regarding PFAS assessments by other agencies, EPA cannot explain ATSDR’s decision to disregard the extensive epidemiologic evidence and its utility in toxicity value derivation. Discussing and comparing decisions across different agencies with different decision contexts, mandates, and guidelines is outside the scope of an IRIS assessment. However, it is important to note that EPA is not alone in using epidemiology data for toxicity value derivation. Other agencies, including the European Food Safety Authority (EFSA) and CalEPA, have used a similar approach.

[underlined: Tier 1 Recommendation 2 of 2]: Panelist recommended: “Consistent with recent conclusions by the Australian government (FSANZ 2021) and the U.S. Agency for Toxic Substances and Disease Registry (ATSDR 2021). Alternatively, the assessment should specifically outline why ATSDR, a federal public health agency of the U.S. HSS/CDC charged with protecting communities from the harmful health effects related to exposure to hazardous substances, is wrong about the epidemiology literature being inadequate for use as the basis for toxicity factors.”

[underlined: EPA Response]: The following quote is from the EPA Cancer guidelines, but applies equally well to non-cancer toxicity value derivation: “Epidemiologic data are extremely valuable in risk assessment because they provide direct evidence on whether a substance is likely to produce cancer in humans, thereby avoiding issues such as: species-to-species inference, extrapolation to exposures relevant to people, effects of concomitant exposures due to lifestyles. Thus, epidemiologic studies typically evaluate agents under more relevant conditions. When human data of high quality and adequate statistical power are available, they are generally preferable over animal data and should be given greater weight in hazard characterization and dose-response assessment, although both can be used.” For more details on use of epidemiology studies for toxicity value for derivation, see 3 of 5 Tier 1 Charge 1a. For discussion on other agency findings, see 26 of 28 Tier 1 Charge 2f.

### G.3.7 External Peer Review Comments on Charge Question 4b

#### Peer Review Comment Summary

One reviewer commented that epidemiology studies should not be used as the basis of a quantitative dose-response assessment due to the potential for residual confounding and that a controlled animal toxicity study should be used as the basis of the quantitative dose-response assessment. The reviewer also commented that a RfD based on decreased serum T4 in Ramhøj et al. (2018) would be an appropriate starting point for a subchronic RfD. One reviewer declined to comment. The tiered comments on Charge Question 4b were:

- 2 Tier 1 Recommended Revisions from one panelist
- 0 Tier 2 Suggested Revisions
- 0 Tier 3 Future Considerations

#### Tier 1 Recommended Revisions

[underlined: Tier 1 Recommendation 1 of 2]: Panelist recommended: “A quality animal PFHxS toxicity study(ies) should be used as the basis of dose-response assessment and subchronic RfD derivation (Tier 1 necessary revision) as such studies are not mixture studies confounded by co-exposures to chemicals with similar chemistry/MOA(s) and toxicity (e.g., other PFAS) that cannot be adequately adjusted for. Unlike the epidemiology studies used in the draft assessment, in animal toxicity studies sufficient to characterize PFHxS dose-response, PFHxS will be a reliable predictor of toxicity due to the absence of confounding by other PFAS that the scientific community has no consensus how to accurately adjust for in epidemiology studies (p. C-1, lines 1–4). The draft assessment currently contains a subchronic (and chronic) RfD based on decreased serum total T4 levels in a high quality Wistar rat study (Ramhøj et al. 2018, Table ES-1), which is a good place to start as the basis of a final subchronic (or chronic) RfD”

[underlined: EPA Response]: The following quote is from the EPA Cancer guidelines, but applies equally well to non-cancer toxicity value derivation: “Epidemiologic data are extremely valuable in risk assessment because they provide direct evidence on whether a substance is likely to produce cancer in humans, thereby avoiding issues such as: species-to-species inference, extrapolation to exposures relevant to people, effects of concomitant exposures due to lifestyles. Thus, epidemiologic studies typically evaluate agents under more relevant conditions. When human data of high quality and adequate statistical power are available, they are generally preferable over animal data and should be given greater weight in hazard characterization and dose-response assessment, although both can be used.” For additional discussion see Tier 1 Recommendation 3 of 5 for Charge 1a).

[underlined: Tier 1 Recommendation 2 of 2]: Panelist recommended: “Consistent with the Australian government (FSANZ 2021) and the U.S. Agency for Toxic Substances and Disease Registry (ATSDR 2021), epidemiology studies should not be used as the basis for PFAS toxicity factors (e.g., subchronic or chronic RfDs). For reasons previously cited under question “2.a” comments, these epidemiology studies should be considered deficient under EPA guidelines (IRIS Handbook; USEPA 2022). Instead, quality animal toxicity studies of PFHxS avoid significant mixture/confounding effect issues that should preclude the use of epidemiology studies, and also allow for selection of critical effect(s) that are entirely attributable to PFHxS, more clearly statistically significantly increased/decreased, and more clearly adverse or more clearly lead to adverse outcomes.”

[underlined: EPA Response]: EPA guidelines outline a preference for well-conducted human studies for derivation of toxicity values when available. The following quote is from the EPA cancer guidelines (2005) but similar language exists in EPA noncancer guidelines and it applies equally well to cancer and non-cancer toxicity value derivation: “Epidemiologic data are extremely valuable in risk assessment because they provide direct evidence on whether a substance is likely to produce cancer in humans, thereby avoiding issues such as: species-to-species inference, extrapolation to exposures relevant to people, effects of concomitant exposures due to lifestyles. Thus, epidemiologic studies typically evaluate agents under more relevant conditions. When human data of high quality and adequate statistical power are available, they are generally preferable over animal data and should be given greater weight in hazard characterization and dose-response assessment, although both can be used.” This preference for human data in toxicity value derivation is reiterated in the IRIS Handbook (2021).

When using epidemiologic studies for hazard identification and dose-response analysis, it is critical to evaluate and transparently document the risk of bias and the potential for insensitivity in the available studies, both at the individual study level and across the body of evidence. The systematic review framework described in the IRIS Handbook is a state-of-the-art method that has been reviewed favorably by the National Academies of Science, Engineering, and Medicine (NASEM 2020). It was developed through an extensive, decade-long engagement with the national and international systematic review community, and the public.

An often-voiced concern regarding use of epidemiologic data in PFAS human health assessments, particularly for toxicity value derivation, is the potential for confounding across PFAS. The general population is typically exposed to a variety of PFAS and it can be difficult to disentangle the independent effect of a single PFAS, although refined evaluations of potential confounding can help. It is important to acknowledge this as a source of uncertainty in the observational epidemiology evidence, but only in conjunction with informative analyses of the likelihood and direction of potential confounding for the specific studies and populations being evaluated. It is not scientifically justified to use a generalized, hypothetical concern over possible confounding as a reason to automatically dismiss epidemiological studies of PFAS exposure, which has been suggested by some individuals even in reference to entire large databases of epidemiological evidence for some health outcomes. Rather, it is necessary to carefully consider the direct evidence on potential confounding based on established epidemiological techniques, and to transparently document these analyses and subsequent decisions for review by qualified experts.

There are standard methods in epidemiology and systematic review to evaluate the potential for confounding within individual studies and across studies. For some PFAS, there are studies in occupational populations or in communities with large water contamination events that are less susceptible to this source of confounding because a single PFAS predominates the exposure. This type of study is largely not available for PFHxS (a contamination event did occur in Ronneby, Sweden, but PFOS was a co-contaminant). Thus, in assessing the potential for confounding by other PFAS, the IRIS PFHxS assessment primarily relied on analysis of results from multipollutant modeling with adjustment for co-exposures through a variety of mixture approaches. While not all of the available studies presented this information, the results in the studies that perform multipollutant modeling can be informative for the body of evidence as a whole. There was also consideration of the correlations between PFHxS and other PFAS in the study populations. As PFAS exposure profiles differ for a variety of reasons (e.g., proximity to manufacturing), these correlations vary across populations; where correlations between PFHxS and another PFAS are low, confounding of the PFHxS results by that PFAS are of lesser concern.

For health outcomes advanced for dose-response assessment based on moderate or robust human evidence conclusions, particularly those with consistent results across different epidemiological studies with heterogeneous populations and exposure scenarios, the potential for any confounding by co-occurring PFAS was judged by EPA as unlikely to explain the identified hazards. This does not eliminate the possibility of confounding existing, and this source of uncertainty is acknowledged in the assessment. However, uncertainty is an inherent part of the risk assessment process, and, in these cases, the evidence was sufficient to reasonably rule out this uncertainty as a substantial contributor to the results. Separately, it is important to note that use of animal data instead of epidemiologic data does not eliminate uncertainty, but rather trades it for a different source (i.e., interspecies extrapolation).

For toxicity value derivation in the PFHxS assessment specifically, the outcome of vaccine response underwent this analysis, and it was determined that confounding was unlikely to explain the observed effects, and further, that adjustment for other PFAS had no impact on the POD (see response for vaccine response for additional detail). In contrast, for other outcomes, such as liver enzymes and serum lipids, the potential for confounding by other PFAS was considered a greater source of uncertainty that prevented the PFHxS human evidence from reaching a judgment of moderate and thus prevented the use of these data to support toxicity values in this assessment.

Regarding PFAS assessments by other agencies, EPA cannot comment on ATSDR’s decisions regarding the extensive epidemiologic evidence for PFHxS and its utility in their toxicity value derivations. Discussing and comparing decisions across different agencies with different decision contexts, mandates, and guidelines is outside the scope of an IRIS assessment. However, it is important to note that EPA is not alone in using epidemiology data for PFAS toxicity value derivation. Other agencies, including the European Food Safety Authority (EFSA) and California EPA (CalEPA), have used a similar approach.

### G.3.8 External Peer Review Comments on Charge Question 4c

#### Peer Review Comment Summary

One reviewer commented that effects selected for deriving the subchronic RfD are appropriate as they represent clear adverse changes that have substantial scientific support (no tier) and another reviewer commented that the developmental immune effects have less uncertainty and lower osRfD compared to the thyroid effects, and as such, the effects selected are appropriate for deriving the subchronic RfD (no tier). One reviewer declined to comment.

There were no recommended or suggested revisions or future considerations for this subsection.

### G.3.9 External Peer Review Comments on Charge Question 4d

#### Peer Review Comment Summary

The majority of reviewers (8 of 9) agreed with EPA’s decision not to derive a subchronic RfC for inhalation exposure based on lack of data. One reviewer commented that derivation of a subchronic RfC should be a priority, particularly for PFHxS and other PFAS with occupational exposures. One reviewer declined to comment. The tiered comments on Charge Question 4d were:

- 0 Tier 1 Recommended Revisions
- 0 Tier 2 Suggested Revisions
- 1 Tier 3 Future Considerations

#### Tier 3 Future Considerations

[underlined: Tier 3 Future considerations 1 of 1] Panel member commented: Inhalation exposures can be important, particularly for workers in certain industries. Derivation of a subchronic RfC should be a priority, particularly for PFHxS and other PFAS with occupational exposures.

[underlined: EPA Response]: EPA acknowledges the utility of an RfC, however the current evidence base lacks the necessary data to inform the derivation of a RfC value for PFHxS.

### G.3.10 Public Comments on Noncancer Toxicity Value Selection and Modeling

Public Comment: One commenter (AWWA) commented “The selection of the critical study for immune effects is not scientifically justified; vaccine response should not be used for deriving an RfD for PFHxS.”

[underlined: EPA Response]: With respect to use of epidemiology studies, see EPA’s response to Charge 1a. (Appendix G.1.1), T[underlined: ier 1 Recommendation 3 of 5. In brief,] a concern for use of epidemiologic data specifically in the PFAS assessments, particularly for toxicity value derivation, is the potential for confounding across the PFAS. The general population is exposed to a variety of PFAS, and it can be difficult to disentangle the independent effect of a single PFAS. It is important to acknowledge this as a source of uncertainty in the observational epidemiology evidence, but only in conjunction with informative discussions on the likelihood and direction of potential confounding for the specific studies and populations being evaluated. It is not scientifically justified to use a hypothetical concern over possible confounding based on limited direct evidence in epidemiological studies of PFAS as a reason to automatically dismiss all epidemiological studies of PFAS exposure, including large databases of evidence for some health outcomes.

There are standard methods in epidemiology and systematic review to evaluate the potential for confounding within individual studies and across studies. For some PFAS, there are studies in occupational populations or in communities with large water contamination events that are less susceptible to this source of confounding because a single PFAS predominates the exposure. This type of study is largely not available for PFHxS (a contamination event did occur in Ronneby, Sweden, but PFOS was a co-contaminant). Thus, in assessing the potential for confounding by other PFAS, the assessment primarily relied on analysis of results from multipollutant modeling with adjustment for co-exposures through a variety of mixture approaches. While not all of the available studies presented this information, the results in the studies that perform multipollutant modeling can be informative for the body of evidence as a whole. There was also consideration of the correlations between PFAS in the study populations as these correlations vary across populations; where correlations are low, confounding is of lesser concern.

As stated in a previous response (7 and 8 of 10 Tier 1 Charge 2a, Appendix G.2.1). ), this approach was supported by a consensus panel during external peer review of the PFOS and PFOA assessments (EPA 2022).

Public Comment: Once commenter (AWWA) commented “The rat model is considered a relevant but conservative basis for human health risk assessment of potential thyroid effects because of the differences in thyroid structure and hormone half-lives (USEPA 2002). However, it should be noted that as a result of these differences, the rodents are much more susceptible to disruption of thyroid function than humans. For example, thyroid effects have been reported for PFOS in the rodent at doses on the order of 1 mg/kg/d (Thibodeaux et al. 2003), but no effects were seen in monkeys dosed with PFOS at 11–17 mg/kg/d (Chang et al. 2017).”

[underlined: EPA Response]: While PFOS was not found to have thyroid effects in the non-human primates in the Chang 2017 study, multiple epidemiological studies on PFOS reported effects on the thyroid. The PFHxS evidence base does not contain any studies of any duration length in non-human primates. As supported by the peer review (see above), EPA has concluded that the available evidence for PFHxS indicates that PFHxS exposure likely causes thyroid effects in humans given sufficient exposure conditions.

Public Comment: One commenter (AWWA) commented “The rationale for using a BMR of ½ standard deviation change from a control mean (BMD½SD) for vaccine response to diphtheria and tetanus vaccine in children is unclear and produces an artificially low RfD. The USEPA justifies this BMR on the grounds that diphtheria and tetanus are serious and sometimes fatal infections. However, diphtheria and tetanus infections are exceedingly rare in the United States and the extra risk of these infections assuming such a shift occurs is extremely small (and perhaps immeasurable). There have been no changes in tetanus or diphtheria infections in dozens of years, due to the success of the childhood vaccine program. The Faroe Island studies used log base 2 transformed data and it is not clear if a BMR of ½ SD change (or even a 1 SD change as suggested in USEPA 2012) from a control mean has any biological significance when the statistically significant epidemiological association is based on log transformed data. Caution is advised when interpreting the shape of the exposure response curve based on log-transformed epidemiological data (Crump, 2006). In addition, vaccine response is highly variable between individuals.

[underlined: EPA Response]: Please see Appendix D.1.

Regarding the question of adversity, while there is some debate regarding the biological significance of small changes in serum antibody levels (Luster et al., 2005; IPCS, 2012; DeWitt et al., 2016; Agarwal and Cunningham-Rundles, 2007), EPA’s interpretation was supported during the external peer review of the PFOS and PFOA Toxicological Reviews (U.S. EPA, 2022c) as well as by the majority of reviewers of the 2024 IRIS PFDA assessment and this IRIS PFHxS Toxicological Review. Vaccine immune titers are functional measures of adaptive immune response and important indicators of clinically relevant immunotoxicity; reduced antibody production is an indication of immunosuppression and may result in increased susceptibility to infectious diseases generally (i.e., not limited to those specifically studied). EPA defines an “adverse effect” as a “biochemical change, functional impairment, or pathologic lesion that affects the performance of the whole organism or reduces an organism’s ability to respond to an additional environmental challenge” (italics added) (U.S. EPA, 2002). Reduced antibody titers are thus considered an appropriate effect for the derivation of a candidate RfD.

Public Comment: commenter (Bruce Allen for 3M; summary) Critique of Budtz-Jorgensen and Grandjean (2018) and U.S. EPA’s Use of Models Derived Therefrom for the PFHxS Assessment. Bruce Allen captured his critique in 3 overarching sections: 1) Methodological errors:” the piecewise approach by Budtz-Jørgesen and Grandjean is fundamentally flawed” therefore EPA’s decision to derive the POD from the estimates from the Budtz-Jorgensen and Grandjean piecewise model was a “poor decision by EPA” according to Bruce Allen. 2) Application Missteps. Bruce Allen evaluated the results (analyses) of the liner model applied to PFHxS by Budtz-Jørgesen and Grandjean and found that these were lacking. Starting with the adjustments for PFOS and PFOA, as regardless of the adjustment he started that neither value was different from 0, nor did any of the other adjustments change fit of the model so as to result in a better model fit. 3)Lastly, Bruce Allen stated that due to “the fundamental problems and implementation issues associated with the basis for EPA’s immune-system-based PODs for PFHxS. Complete re-analysis is necessary for those BMDs.”

[underlined: EPA Response]: EPA reviewed the comments from Bruce Allen (sponsored by 3M). On point #1: This point concerns the association between serum concentrations of PFHxS in 5 year old children and their tetanus antibody concentrations at age 7 years. Three model shapes were evaluated by Budtz-Jørgensen and Grandjean (2018a) using likelihood ratio tests: a linear model, a piecewise-linear model with a knot at the median PFHxS concentration, and a logarithmic function. The logarithmic functions did not fit better than the piecewise-linear functions (Budtz-Jørgensen and Grandjean, 2018a). There was evidence that the piecewise-linear model fit better than the linear model for both the PFHxS exposure model without adjustment for PFOS and PFOA (p = 0.002; see Budtz-Jørgensen and Grandjean (2018b) Table 3) and for the model that did adjust for PFOS and PFOA (p = 0.05). The null hypothesis test here was that the linear model would fit better than the piecewise linear model; p-values <= 0.05 are considered to be statistically significant rejections of the null hypothesis – meaning that there is evidence that the piecewise-linear model fit these data better than the linear model. Bruce Allen does not cite these p-values for PFHxS measures at age 5 years and tetanus antibody concentrations measured at age 7 years which indicate that the piecewise model fits better.

Allen argues that since there were 40 different tests of linear vs. piecewise-linear fit and “[t]hese results strongly suggest that the piecewise model is not better at describing the totality of the data they considered.” However, Budtz-Jørgensen and Grandjean (2018a) were not assessing which model shape fit best globally across these 40 analyses, rather they allowed that each set of age groups and antibody types could have its own best shape. In the case of tetanus and PFHxS measured at age 5 years, the results clearly showed that the piecewise-linear fit better than the linear model. Allen shows an example with 10 data points and claims that the method of fitting piecewise-linear model “fails to get a reasonable estimate.” Examination of Allen’s Figure 2 shows that of the 10 data points selected, 8/10 have exposure values greater than the median of what Allen assumes to be the true model. This has the effect of yielding a sample set with a median value greater than the true (but unobserved) median thereby forcing the upper slope of the piecewise-linear mode to change direction. Allen then states that adding more data would not address the issue and Allen adds four more points for a total of 14 points of which 11/14 are above the true median yielding the same result. Examples with 10 or 14 points that appear to be skewed right in both instances are not convincing. The actual data analyzed in Budtz-Jørgensen and Grandjean (2018b) are based on more than 400 children. Further, the point of fitting piecewise-linear models is to assess if the slope beneath the median (the lower-exposure slope) fits differently than the linear model. EPA’s interest in deriving toxicity values is about the shape of the association in the lower region of exposures. EPA does not find that the commenter’s argument supports a conclusion that piecewise-linear models are fundamentally flawed.

Regarding point #2: In responding to point #1, EPA showed that the piecewise-linear model fit better than the linear model of serum PFHxS at age 5 years and antibody concentration measured at age 7 years. Allen alleges “Application Missteps” using an example based on the linear model that EPA has just shown does not fit these data as well as the piecewise-linear model and then Allen claims that “in not one of these analyses – whether for tetanus or diphtheria and whether adjusted for PFOA and PFOS or not – is the coefficient for PFHxS significantly different from 0.” EPA used the piecewise-linear model result because they fit better than the linear model results that Allen presents. The observation by Allen that a poor fitting model fits poorly is not relevant, nor does it call the model result that EPA did use into question.

Regarding point #3: Bruce Allen stated that due to “the fundamental problems and implementation issues associated with the basis for EPA’s immune-system-based PODs for PFHxS. Complete re-analysis is necessary for those BMDs.” Allen’s argument that piecewise-linear models are fundamentally flawed is not supported. His application of the results of the poorly fitting linear model results for PFHxS and antibody concentrations that EPA already showed to be a poorer fit to these data compared to piecewise-linear model does not support his call for “complete re-analysis.”

Regarding Allen’s proposal to use the hybrid approach to derived toxicity values: Allen proposed two different cut-points for defining adversity (0.01 and 0.1 IU/mL). As stated in Appendix D.1, EPA cited WHO Galazka et al. (1993) as evidence that there is not a protective level of antibody concentrations and without such a consensus, EPA followed its Technical Guidance to use a 1 SD and ½ SD change as the benchmark response (rather than the hybrid approach). Allen’s own citation of two different cut-points for adversity (0.01 IU/mL and 0.1 IU/mL) and his statement “acknowledging that there is no hard-and-fast bright line at which complete protection switches to absolute susceptibility” supports EPA’s justification to not use the hybrid approach and to use the 1 SD and ½ SD change approach.

Lastly, Allen’s application of the hybrid approach to the linear model results that EPA has already shown to fit poorly in comparison to the piecewise-linear model results cannot be used to claim that alternative analyses “would increase the PODs for immunological endpoint associated with PFHxS exposure by at least an order of magnitude.”

Public Comment: commenter (AWWA) It would not be appropriate to attempt oral-to-inhalation extrapolation for PFHxS to obtain a RFC, due to the significant differences in the processes determining uptake by the two routes and the lack of a validated inhalation PBPK model for PFHxS.

[underlined: EPA Response]: No response is necessary. EPA acknowledges the utility of an RfC, however EPA agrees with AWWA that the current evidence base lacks the necessary data to inform the derivation of a RfC value for PFHxS. EPA’s decision not to derive an RfC is outlined in Section 5.2.3 of the IRIS Toxicological Review of PFHxS.

Public Comment: commenter (AWWA) commented “As discussed in the responses to question 3, the selection of vaccine response in humans was not scientifically justified but thyroid effects in rats was scientifically justified as a conservative basis for a subchronic RfD.

Vaccine response to tetanus (or diphtheria) boosters should not be used for deriving an RfD for PFHxS and specifically, the Faroe Islands birth cohort data for tetanus antibody titers measured at age 7 in relation to PFHxS concentrations at age 5 should not be used to establish a RfD. The use of vaccine response can be used to screen for potential immunotoxicity, but in the absence of additional data on immunotoxicity, a decreased response to vaccine should not be used as a surrogate of immunosuppression. There is a wide variation in antibody titer concentrations between individuals (and within individuals over time). It is unclear whether there is a population-level shift in the distribution of anti-tetanus and anti-diphtheria toxoids when the antibody concentrations have been log transformed. In addition, the USEPA stated that there is little evidence that PFHxS exposure is associated with an increased risk of infections or frequency or persistence of infections.

The lifetime and subchronic RfD for PFHxS calculated by the USEPA was 2 × 10−10 ug/kg-day. This value is artificially low and considerably lower than that calculated for PFOA and PFOS which suggests that PFHxS is more toxic than either PFOA or PFOS. The USEPA used a POD of 2.82 × 10−4 mg/L in serum (and a BMDL½SD). The USEPA justified using a BMDL½SD because the effect was seen in children (developmental effect). This seems unnecessarily conservative given the substantial variability between individuals in response to vaccine.

[underlined: EPA Response]: Please see Appendix D.1

Regarding the question of adversity, while there is some debate regarding the biological significance of small changes in serum antibody levels (Luster et al., 2005; IPCS, 2012; DeWitt et al., 2016; Agarwal and Cunningham-Rundles, 2007), EPA’s interpretation was supported during the external peer review of the PFOS and PFOA Toxicological Reviews (U.S. EPA, 2022c) as well as by the majority of reviewers of the 2024 IRIS PFDA assessment and this IRIS PFHxS Toxicological Review. Vaccine immune titers are functional measures of adaptive immune response and important indicators of clinically relevant immunotoxicity; reduced antibody production is an indication of immunosuppression and may result in increased susceptibility to infectious diseases generally (i.e., not limited to those specifically studied). EPA defines an “adverse effect” as a “biochemical change, functional impairment, or pathologic lesion that affects the performance of the whole organism or reduces an organism’s ability to respond to an additional environmental challenge” (italics added) (U.S. EPA, 2002). Reduced antibody titers are thus considered an appropriate effect for the derivation of a candidate RfD.

Public Comment: commenter (AWWA) A BMR ½ SD from a control mean for log-transformed vaccine response is not appropriate and it is unclear what it means at the population level. Nevertheless, it is likely to be small relative to “normal” levels of titers which are highly variable between individuals. Response to a booster tetanus and diphtheria (vaccine titers at age 7 in response to PFHxS at age 5) is not the same as a primary response to an antigen. The rat model is considered relevant yet conservative for human health risk assessment of potential thyroid effects because of the differences in thyroid structure and hormone half-lives (USEPA 2002). However, it should be noted that as a result of these differences, the rodents are much more susceptible to disruption of thyroid function than humans. For example, thyroid effects have been reported for PFOS in the rodent at doses on the order of 1 mg/kg/d (Thibodeaux et al. 2003), but no effects were seen in monkeys dosed with PFOS at 11–17 mg/kg/d (Chang et al. 2017)

[underlined: EPA Response]: Please see response to [underlined: Panel Member Recommended Revision] (3 of 8 Tier 1 Charge 3d).

## G.4 CHARGE QUESTIONS 5 AND 6 NONCANCER TOXICITY VALUE PHARMACOKINETIC EXTRAPOLATION AND UNCERTAINTY FACTORS

Appendix E describes a Bayesian pharmacokinetic (PK) analysis of the available data for mice, rats, and monkeys, in order to obtain key PK parameters with rigorous confidence ranges. Appendix E also describes the application of the resulting parameters in a one compartment (1-C) PK model for rats to evaluate its potential for use in extrapolating PFHxS toxicity data to humans. Section 3.1 evaluates and synthesizes the PK data in relevant species and sexes, and among human life stages, up to the derivation of key PK parameters used in the subsequent analysis. The evaluation of existing PBPK models and the 1-C PK model found that the PBPK model was not sufficiently reliable for use. While the 1-C PK model significantly overpredicts concentrations observed in adult male and female rats in the NTP bioassay at high doses (see Figure E-8 of Appendix E), the predictions were considered by EPA to be acceptably close to the observed NTP bioassay concentrations in the range of the rat PODs being evaluated (0.684 mg/kg-d in male rats, and 0.051 and 5.5 mg/kg-d in female rats).

5a Is the decision and method for applying DDEFs for rat-human extrapolation scientifically justified, given the available science or should the EPA give greater weight to the 1-C PK model, despite the noted uncertainties? Should the choice of extrapolation method depend on the rat sex in which an endpoint is observed (or when dosing occurred to dams for developmental effects, in which case the adult female PK is considered relevant)? Should EPA instead use direct interpolation of the NTP end-of- study concentration data (which are sex-specific) to estimate internal doses for that bioassay in particular? Please provide some details on your rationale for a preferred approach.
5b Is use of the human sex- and lifestage-specific clearance values to estimate HEDs from internal dose PODs in humans scientifically justified? Specifically, should EPA include estimates of total CL from studies that only measured urinary clearance, requiring an estimation of fecal (and other pathway) clearance, or only use estimates based on empirical half-lives or estimates total CL based on estimated exposure levels that do not require estimation of fecal clearance? Please provide some details supporting your recommendation.
5c Have the uncertainties in the DDEFs and human CL been adequately evaluated and described? In answering this question, please explicitly consider EPA’s approach to adjusting for menstrual fluid loss in the draft assessment. If the estimated menstrual fluid clearance as a specific mechanism is not considered reliable, should EPA adjust for empirical differences observed between 1) women of childbearing age and 2) men and younger and older women, such as reported by (Jain, 2022), discussed in Section 3.1.4/Humans/Sex differences in human PFHxS.
6 EPA has evaluated and applied where appropriate uncertainty factors to account for intraspecies variability (UF_H_), interspecies differences (UF_A_), database limitations (UF_D_), duration (UF_S_), and LOAEL-to-NOAEL extrapolation (UF_L_) for PFHxS.
  a. Is uncertainty in the derivation of the toxicity values scientifically justified and clearly described? Please describe and provide comments, if needed.
    i. Please comment specifically on whether the methods used to derive toxicity values for PFHxS appropriately account for uncertainties in evaluating the pharmacokinetic differences between the experimental animal data and humans.
  b. Please specifically comment on whether use of the intra-human uncertainty factor, UF_H_ = 10, in combination with the selected sex- and lifestage-specific human CL values, appropriately accounts for both the pharmacokinetic and pharmacodynamic uncertainties and differences (variability) among humans?
  c. For [underlined: immune effects], a UF_S_ of 1 was selected. A UFs of 10 was not considered as the developmental period is recognized as a susceptible lifestage for these types of effects and therefore exposure during this time window can be considered more relevant than exposure in adulthood (U.S. EPA, 1991). Also important is the fact that, given PFHXS long half-life and the expectation that the children and their mothers have been exposed to elevated levels of PFHxS for many years, the observed effects on immune response are considered to be the result of a cumulative, prolonged exposure. Uncertainties with regards to additional susceptible life stages (e.g., old age) are addressed as part of the UF_D._ Does the provided scientific rationale support this decision? If not, please explain.

### G.4.1 External Peer Review Comments on Charge Question 5a

#### Peer Review Comment Summary

Two reviewers agreed with EPA’s decision and consider it appropriate and scientifically justified. One reviewer commented that GI excretion is important for sulfonates but did not comment on how this may affect calculations. Another reviewer commented that gastrointestinal excretion is important for sulfonates but did not comment on how this may affect these calculations (not tiered). One reviewer suggested that EPA add a summary paragraph to the end of Sections E-1 and E-2 to increase the clarity of the document. The same reviewer also commented that tables 3-3 and 3-4 should include values of half-lives associates with each of the listed clearance values. Another reviewer commented that if the uncertainties associated with the use of DDEFs are greater than those associated with the use of the 1-C PK model and the comparability of PODs does not more than offset the greater uncertainty, EPA should reconsider the decision not to use a 1-C PK model. The reviewer further commented that EPA should clarify the text around over-prediction of the serum concentration time-course. The same reviewer also commented that EPA should not give greater weight to the 1-C PK model due to the noted uncertainties (not tiered). One reviewer suggested EPA add additional context about the Bayesian model in Appendix E. Four of nine reviewers declined to provide comments on this question. The tiered comments on Charge Question 5a were:

- 4 Tier 1 Recommended Revisions from three panel members
- 7 Tier 2 Suggested Revisions from three panel members
- 3 Tier 3 Future Considerations from two panel members

#### Tier 1 Recommended Revisions

[underlined: Tier 1 Recommendation 1 of 4]: Panelist recommended: Modify Tables 3-3 and 3-4 to include values of half-lives associated with each of the clearance values listed in these tables

[underlined: EPA Response]: Half-lives have been added as suggested, also to Table 3-5.

[underlined: Tier 1 Recommendation 2 of 4]: Panelist recommended “The draft provides a rationale for applying DDEFs and rejecting use of a 1-C PK model. For example, p. 3–44 (lines 28–34) indicates that [emphasis added]…”a reliable PK model for PFHxS is not considered to be in the realm of available science. Further, use of the empirical one-compartment PK model for some endpoints and a of data-derived extrapolation factor (DDEF) for others would create inconsistency in the extrapolation approach. This inconsistency would hinder the comparison between different candidate points of departure and the failure of the model in some instances lowers the confidence in model predictions, even for dose ranges where the model appears to be performing well. Therefore, a PK model was not used for dosimetric extrapolation. “In my opinion, failure of the model in some instances lowering confidence in predictions even for dose ranges where the model performs well appears to be a weak consideration and not even necessarily a correct assumption or inference. Accordingly, if EPA has determined that: (1) the uncertainties associated with use of DDEFs are not greater than (or at least not appreciably greater than) those associated with use of the 1-C PK model; and (2) greater comparability of PODs across endpoints is an overriding consideration; then their decision to use DDEFs is justified. Otherwise, i.e., if the uncertainties associated with use of DDEFs are appreciably greater than those associated with use of the 1-C PK model and the comparability of PODs consideration does not more than offset the greater uncertainty, EPA should revisit their decision not to use a 1-C PK model.

[underlined: EPA Response]: As EPA’s approach to analyzing PFAS PK has evolved, it has concluded that a hybrid or mixed approach such as suggested here is reasonable. In the absence of other options, use of the PK model (now two-compartments) to evaluate internal doses at low concentrations for the NTP bioassay is a better option than use of the DDEF. However, the revised assessment now uses a third option, interpolation of the NTP bioassay data as described in Appendix E.2, which EPA considers to be at least similarly accurate to use of the PK model. Further, this third option does not require identification of a dose level above which the model is not applicable and a DDEF should be used instead. The plot comparing PK predictions to the NTP data (Figure E-8) has been revised to show the steady-state concentration for the lowest dose, so the assumption of steady-state in the DDEF can be compared to model results, as suggested by this comment. However, in the absence of any PK data for the multigeneration rat bioassay (Ramhoj et al., 2018) which can be used to evaluate model predictions (vs. a steady-state assumption), EPA did not consider it appropriate to extrapolate the model to estimation of internal doses for that study and it was not possible to estimate doses by interpolation. So, for those endpoints the DDEF approach is still applied.

[underlined: Tier 1 Recommendation 3 of 4]: Panelist recommended Although this charge question concerns rats, the draft states that the mouse model did not over-predict the serum concentration time-course (p. 3–41, lines 6–7). However, the referenced Figure E-5 shows that the predicted line and its 90% credible interval fall both above and below various datapoints. EPA should clarify the referenced text.

[underlined: EPA Response]: The text has been revised to more indicate the intent: if in fact bioavailability was less than 100% the model (assuming 100% uptake) would have over-predicted the data. That this did not occur, as indicated by the comment, supports the assumption.

[underlined: Tier 1 Recommendation 4 of 4]: Panelist recommended On Page 3-46, Table 3-7, the word “CLA” should be changed to “CLA.”

[underlined: EPA Response]: There appears to be a typo from panel member reviewer, CLA and CLA are the same word, however we have taken another look at Table 3-7 and will be adding definition of CL_A_ to the table footnotes.

#### Tier 2 Suggested Revisions

[underlined: Tier 2 Suggested revisions 1 of 7]: Panel Member Suggested Revision for Appendix E is to add one summary paragraph to the end of Section E-1 (page E-10) and to E-2 (page E-15) that provide the bottom-line summary of findings. This would facilitate the user of these documents to link directly to Section 3 and show the connections between the detailed analysis support materials with the main discussion and conclusions in the overall review document.

[underlined: EPA Response]: Summary paragraphs have been added to E.1 and E.2 as suggested.

[underlined: Tier 2 Suggested revisions 2 of 7]: Panel Member Suggested Revision Expand the discussion of the httk approach (page 3-37, lines 12–19) to indicate ongoing modifications by EPA that aim to address issues critical to PFAS (such as renal reabsorption). For example, such information was presented by Wambaugh et al. at the 2024 Annual meeting of the Society of Toxicology (SOT) under the title “Applying High Throughput Toxicokinetics (HTTK) to Per- and Polyfluoro Alkyl Substances (PFAS).”

[underlined: EPA Response]: Many research groups presented work on ongoing research on PFAS PK at SOT 2024. It is not the practice for an IRIS assessment to describe and cite meeting abstracts/presentations as these have not been finalized and peer-reviewed. Although httk is a component of EPA/ORD’s ongoing research on PFAS from a companion center, creating an exception to our inclusion rules would leave the IRIS open to criticism of being selective in the application of those rules.

[underlined: Tier 2 Suggested revisions 3 of 7]: Panel Member Suggested Revision The model equations are already provided. However, the model code file should also be presented to enable readers or users to reproduce the results and potentially apply the model. For example, in one of recent risk assessment documents for PFAS from European Food Safety Authority (EFSA, 2018), a PBPK model was used, and the entire model code was provided in the document.

[underlined: EPA Response]: The model code file is being provided with the final draft.

[underlined: Tier 2 Suggested revisions 4 of 7]: Panel Member Suggested Revision In terms of prior distributions of the PK parameters, there are three types: weekly informed, broad, and uninformed. However, based on Table E-2, the ranges of these different types of priors are very similar. It is unclear why weakly informed priors were selected.

[underlined: EPA Response]: Through a sensitivity analysis of the selection of Bayesian priors, EPA found that the assumptions for the pharmacokinetic parameter prior distributions, described in Table E-2, had no impact on the central estimates of the posterior population means. Text stating this, along with the rationale for why the weakly informed priors were ultimately selected was added to Appendix E.1.

[underlined: Tier 2 Suggested revisions 5 of 7]: Panel Member Suggested Revision Since it is known that the PK of PFHxS is sex-dependent, did the researchers conduct the Bayesian analysis using male-specific data and female-specific data separately in each species? The PK parameter values are not presented for each sex in each species; thus it is difficult to evaluate the sex-specific dosimetry in each species.

[underlined: EPA Response]: As now stated in “Summary of study-specific clearance values and model fits” in Appendix E-1, the analysis was performed separately for each species/sex. Table 3-6 in the main text has a complete summary of mice, rats, monkey male/female PK parameters (Bayesian parameter means and Cis for clearance, Vd, and half-lives). Results listed in Tables 3-1 (Vd) and 3-3 (clearance) are likewise provided separately for each species and sex. We regret this was not clear in the draft for Appendix E-1.

[underlined: Tier 2 Suggested revisions 6 of 7]: Panel Member Suggested Revision The convergence of the Bayesian analysis is not clear. It is said that convergence was assessed using a potential scale reduction factor with a maximum threshold of (R ^) = 1.05 (Page E-5). However, the convergence results were not presented. The trace plots were not provided, either.

[underlined: EPA Response]: Convergence results, including trace plots and posterior distributions, have been added to Appendix E-1.

[underlined: Tier 2 Suggested revisions 7 of 7]: Panel Member Suggested Revision Additionally, the US CDC published a PopPK model for PFAS in humans, and they converted their model to a web dashboard (i.e., PFAS Blood Level Estimation Tool), where users can use it to predict blood level of different PFAS based on drinking water concentrations of one or more of the following PFAS: PFOA, PFOS, PFHxS, or PFNA (Lynch et al. 2023). It is suggested that this model be evaluated to see if it may be helpful for the current risk assessment.

[underlined: EPA Response]: The U.S. EPA has been in regular communication with ATSDR, who developed the tool. ATSDR informed us that the tool uses the PK parameters and model described by Chui et al. (2022), which is addressed in the toxicological review with results incorporated into EPA’s analysis. Hence, this web dashboard is an application of a previously described model and does not present new science in terms of the PK model structure or parameter values. Therefore, further consideration of this tool was not considered impactful to the assessment. EPA has added this tool to Appendix Table B-2 to document consideration of this tool.

#### Tier 3 Future Considerations

[underlined: Tier 3 Future considerations 1 of 3] Panel member commented: Section 3.1 describes three published PBPK models for PHFxS (Kim et al. 2018; Fabrega et al. 2015; Sweeney, 2022). Each model has its respective limitations and uncertainties that prevent the EPA from using it in this risk assessment. However, among these three published PBPK models, the one by Sweeney (2022) seems to be the most confident one. The noted limitations of the Sweeney (2022) model appear to be addressable. Specifically, the mass-balance error involving the unbound fraction in plasma (CAFREE) can be fixed. The model can then be re-calibrated. Once recalibrated, it is anticipated that the model predictions will be improved. This will take less time compared to building a Bayesian PK model described in Appendix E. Since this model is from a single author (Dr. Lisa Sweeney), she should be consulted, and she can update the model if needed.

[underlined: EPA Response]: EPA ORD staff contacted Dr. Sweeney as soon as they became aware of the model and communicated EPA’s concerns regarding the issue with free fraction in the plasma but did not receive a response to the email sent. The Bayesian calibration described in Appendix E-1 is part of a larger EPA research effort to analyze data for multiple PFAS. But more critically, EPA’s analysis makes use of the fact that the classical one- or two-compartment PK model structure being used has an analytical solution, i.e., does not require numerical solution, which vastly reduces the computational time required to achieve convergence. Hence, EPA does not agree that recalibrating the Sweeney model would be faster or easier. Further, the Sweeney model was only calibrated for human adults, making its application limited -- it could not be used to estimate dosimetry in adult rats, let alone the multigenerational rat bioassay. Finally, while EPA did evaluate possible recalibration of the Kim et al. rat PBPK model to address the issue for that model, such recalibration would require change the serum binding parameters significantly from those measured in-vitro, with no experimental validation that in fact the CAFREE was that much lower than reported. EPA continues to believe that the hypothesis underlying these models is thereby proven to be incorrect and that in order to obtain a model that can reliably predict results of exposures outside the range of calibration, any new hypotheses used to replace the existing one must first be validated with experimental data. Such experimental validation was not feasible in the time available to create the draft document and bring it to peer review. This must be a matter for future research.

[underlined: Tier 3 Future considerations 2 of 3] Panel member commented: Another common weakness of these three published PBPK models is that they are focused on adults, but do not consider sensitive life stages, such as fetal, neonatal, pregnant, and lactating periods. In this regard, there are published PBPK models for PFOS in rats and humans of different life stages, including adulthood, fetal, neonatal, pregnant, and lactating periods (Chou and Lin, 2019; Chou and Lin, 2021). It is suggested that EPA should develop a life-stage PBPK model for PFHxS based on existing PBPK models for the well-studied PFAS compound PFOS (Chou and Lin, 2019; Chou and Lin, 2021).

[underlined: EPA Response]: The adaptation of models such as those cited may be considered within the scope of the PFHxS review and timeframe for completion. EPA explored adaptation of a generic human gestational PK model (Kapraun et al., 2022), which also address the full range of lifestages, including pregnancy and lactation, but the application of this approach to PFHxS was not successful (see Appendix E.2). The failure is due in part to the fact that the Kapraun et al. (2022) model was only created to describe disposition of chemicals for which clearance is constant while the PFHxS data clearly indicate more rapid clearance at higher doses than at low doses, which is attributed to saturable renal resorption, a mechanism not included in the model. Further model development was not considered feasible in the time frame for completing the assessment.

[underlined: Tier 3 Future considerations 3 of 3] Panel member commented: “EPA should consider in the future a systematic effort for developing and evaluating multispecies PBPK models for PFHxS (and other PFAS). The PBPK model “templates” developed by Bernstein et al. (2021) provide a foundation for such an effort.”

[underlined: EPA Response]: EPA expects to continue its research on PBPK modeling of PFAS with some research currently in progress. In previous attempts to model existing data, hypotheses were generated which are consistent with the data, such as that exhalation can be a significant route of elimination for slowly excreted PFAS, that would likely require experimental validation before they could be implemented for a tox review. Hence, the general suggestion can only be achieved to a limited extent by CPAD/IRIS researchers but will require collaboration with and the resources of laboratory staff at the EPA or in collaborating institutions.

### G.4.2 External Peer Review Comments on Charge Question 5b

#### Peer Review Comment Summary

One reviewer agreed that EPA’s decision was scientifically justified. Another reviewer commented that for humans, sex differences begin to appear around ages 11–12. Further, the same reviewer commented that menstruation is not the only factor influencing sex differences in serum concentrations. One reviewer commented that it is appropriate for the HED calculation method to depend on the human sex and/or lifestage in which the endpoint is observed. Another reviewer commented that the use of human sex- and lifestage-specific clearance values to estimate HEDs from internal dose PODs in human is scientifically justified. Four of nine reviewers declined to provide comments on this question. The tiered comments on Charge Question 5b were:

- 0 Tier 1 Recommended Revisions
- 1 Tier 2 Suggested Revisions
- 0 Tier 3 Future Considerations
- 2 not tiered comments (interpreted as Future Considerations) from one panel member

#### Tier 2 Suggested Revisions

[underlined: Tier 2 Suggested revisions 1 of 1]: Panel Member Suggested Revision to ensure in the future that all health endpoint discussions include a statement about Mechanistic Evidence and Supplemental Information to ensure that this category of evidence had been evaluated for each endpoint even if the statement is that no evidence was found. An example where inclusion of this section would have been important in the development endpoints section, is the discussion on page 3-180 lines 10–17 that thyroid effects are discussed separately yet are of potential mechanistically relevant for the discussion of developmental impacts such as AGD, growth and pup viability.

[underlined: EPA Response]: A synthesis of mechanistic effects related to thyroid hormones and development is described in Section 3.2.1. To minimize redundancy, the synthesis of the developmental effects section was updated to refer the audience to the synthesis of the available mechanistic evidence on PFHxS-induced alterations in thyroid hormones.

#### Tier 3 Future Considerations

[underlined: Not Tiered comments 1 of 2]: “for humans, ages 11 instead of 15 and 61 instead of 50 would be more appropriate lifestage-specific ages.”

[underlined: EPA Response]: The comment appears to refer to the age range of the younger women group analyzed by Li et al. (2022), which the EPA describes in the review. The age-range selected by the EPA from the NHANES data to evaluate male-female differences (20–52) was based on the availability of samples identified as from women not previously pregnant (not reported for age < 20) and the stability of the observational data up to age 52 (Figure 3-3).

[underlined: Not Tiered comments 2 of 2]: Menstruation is not the only factor influencing sex differences in serum concentrations.

[underlined: EPA Response]: That other factors may play a role, including differences in exposure, is noted by the EPA in “Sex differences in human PFHxS PK.”

### G.4.3 External Peer Review Comments on Charge Question 5c

#### Peer Review Tier Summary 5c

One reviewer commented that the uncertainties in the DDEFs and human CL were adequately described and evaluated. Another reviewer commented that the approach used should be protective of all women, including those who do not menstruate due to amenorrhea or hormonal birth control. A separate reviewer similarly suggested adding a discussion of the variability in the US female population that experience amenorrhea or light periods or other events that would affect clearance such as pregnancy and loss of placenta. One reviewer commented that EPA should adjust for menstrual fluid clearance if estimates are within reason and not expected to significantly overestimate clearance from menstruation, and that the document would benefit from a more focused discussion that is identified as discussing uncertainties in the DDEFs and human CL. One reviewer commented that the uncertainties in the human CL were adequately evaluated and described, but the uncertainties in the DDEFs were not adequately evaluated or described (no tier). The same reviewer further commented that relying on Verner and Longnecker (2015) for the menstrual fluid clearance rate when an additional study was available for more information was not sufficient. Three reviewers declined to provide comments on this question. The tiered comments on Charge Question 5c were:

- 4 Tier 1 Recommended Revisions from two panel members
- 2 Tier 2 Suggested Revisions from two panel members
- 5 Tier 3 Future Considerations (including 3 not tiered comments) from four panelists

#### Tier 1 Suggested Revision

[underlined: Tier 1 Recommendation 1 of 4]: Panelist recommended: “While pharmacokinetic modeling is not my main area of expertise, please see my comments in 1a citing studies on frequency of women of childbearing age with low or absent menstruation. The approach used should be protective of all women, including those who do not menstruate due to amenorrhea or use of hormonal birth control.”

[underlined: EPA Response]: A discussion of the prevalence of amenorrhea and the use and effect of hormonal contraception has been added to “Sex differences in human PFHxS PK” in 3.1.4 Excretion. It is noted, though, that the data on amenorrhea prevalence are over 40–50 years old, with the more recent of the two studies being specific to college students. Since the analysis was revised to use only data from never-pregnant women, pregnancy and the loss of placenta are not factors in the calculation (also now stated in this section).

[underlined: Tier 1 Recommendation 2 of 4]: Panelist recommended: “Accordingly, EPA appears to be taking a reasoned approach to adjusting for menstrual fluid loss. EPA should adjust for menstrual fluid clearance if estimates are within reason and not expected to significantly overestimate clearance from this specific mechanism.”

[underlined: EPA Response]: EPA appreciates the comment. Responses to comments from above and added text address the concern of population variability in this factor.

[underlined: Two related Tier 1 comments from one panel member]:

- “In beginning to answer the charge question, “Have the uncertainties in the DDEFs and human CL been adequately evaluated and described?,” it was not readily apparent which, if any, specific section of the draft is dedicated to discussing such uncertainties. Consequently, it appears that draft should have a section or subsection that is specifically identified as discussing uncertainties in the DDEFs and human CL.”
- “While comparisons to predictions based on allometric scaling (i.e., BW^0.75) are also made (p. 3-333, lines 16–31), such comparisons are not used to assess uncertainty in the human CL estimates but rather to demonstrate that allometric scaling should not be relied upon. The draft would benefit from a more focused section or subsection that is specifically identified as discussing uncertainties in the DDEFs and human CL.”

[underlined: EPA Response]: The section previously titled, “Uncertainty in HED Calculations” at the end of 3.1.7 has been expanded and renamed, “Uncertainty in Clearance, DDEF and HED Calculations” to reflect the inclusion of these quantities.

#### Tier 2 Suggested Revisions

[underlined: Tier 2 Suggested revisions 1 of 2]: Panel Member Suggested Revision reviewer requested ‘[EPA include a few sentences that 1) indicate the variability in US female population that experience amenorrhea or light periods which would support the use of variability in this factor and 2) some indication of other factors that might affect these calculations such as percentage of women with pregnancy and loss of placenta, as it would be hypothesized that such loss would also affect clearance.”

[underlined: EPA Response]: A discussion of the prevalence of amenorrhea and the use and effect of hormonal contraception has been added to “Sex differences in human PFHxS PK” in 3.1.4 Excretion. It is noted, though, that the data on amenorrhea prevalence are over 40–50 years old, with the more recent of the two studies being specific to college students. Since the analysis was revised to use only data from never-pregnant women, pregnancy and the loss of placenta are not factors in the calculation (also now stated in this section).

[underlined: Tier 2 Suggested revisions 2 of 2]: Panel Member Suggested Revision It is important and reasonable to consider menstrual fluid clearance as a specific mechanism in the calculation of total clearance for women of childbearing age. Right now, the estimate of menstrual fluid clearance of 0.033 mL/kg/day is based on a single study by Verner and Longnecker (2015). It is mentioned that this value appears to be consistent with the empirical comparison of PFHxS serum concentrations in men and women by Jain and Ducatman, 2022 (Page 3-33). This description is not sufficient. If possible, efforts should be made to calculate menstrual fluid loss from Jain and Ducatman, 2022, and then compare the value with that from Verner and Longnecker (2015). If a direct calculation is not possible, then further information is needed to justify why it appears to be consistent between these two studies.

[underlined: EPA Response]: The impact of menstrual associated clearance is now calculated from NHANES data which were also analyzed by Jain and Ducatman (2022), although restricted to never-pregnant women, as described in Sex differences in human PFHxS PK (3.1.7). The resulting clearance is 0.031 mL/kg-d and is now used instead of the value from Verner and Longnecker.

#### Tier 3 Future Considerations

[underlined: Tier 3 Future considerations 1 of 2] Panel member commented: ‘Suggestive association (p=VALUE)’ can be used to describe a non-statistically significant association.

[underlined: EPA Response]: EPA intentionally does not restrict its consideration on relevance of findings to p-values and statistical significance (U.S. EPA, 2022b), so is not inclined to make the suggested revisions. We provided effect estimates and 95% CIs in the developmental section as they are more informative and allow us to compare for consistency, potential for bias, and precision.

[underlined: Tier 3 Future considerations 2 of 2] Panel member commented: Please consider a clear statement that EPA/IRIS is interested in maternal-child studies that begin with pre-pregnancy measures of exposure for developmental outcomes. (This is Tier three because getting the word out could be in other venues than this document.) The fluid shifts of pregnancy will make interpretation of serum biomarkers more difficult unless they are obtained prepregnancy or in the first weeks of pregnancy.

[underlined: EPA Response]: EPA agrees and noted in our published meta-analyses that studies with earlier sampling (including preconception) could help inform the potential impact of hemodynamics.

[underlined: Not Tiered Comments 1 of 3] Panel member commented: It is appropriate for the HED calculation method to depend on the human sex and/or lifestage in which the endpoint is observed.

[underlined: EPA Response]: No response needed because the comment is supportive of EPA’s approach.

[underlined: Not Tiered Comments 2 of 3] The human CL were adequately evaluated and described, but the uncertainties in the DDEFs were not adequately evaluated or described.

[underlined: EPA Response]: The final Section of 3.1.7 was renamed to “Uncertainty in Clearance, DDEF and HED Calculations” and the section has been expanded to include an estimate of the DDEF uncertainty.

[underlined: Not Tiered Comments 3 of 3] The document should emphasize reabsorption as an explanation for the long half-life of PFHxS and its slow excretion kinetics.

[underlined: EPA Response]: The role of resorption is noted in multiple places in Sections 3.1.4, 3.1.5 and 3.1.6.

### G.4.4 External Peer Review Comments on Charge Questions 6 (a to c)

#### Peer Review Comment Summary

All the reviewers that commented on this question agreed that the selected approaches for incorporating uncertainty in the derivation of the toxicity values is scientifically justified and clearly described (6a); the selected approach of using an intra-human uncertainty factor of 10 alongside the sex- and lifestage-specific human CL values (6b); and that the scientific rationale supports application of a UFS of 1 (6c). However, one reviewer commented that the wrong subchronic RfD for immune effects was used in Table ES-1 (6a) and another provided an untiered comment that the decision is appropriate based on the scientific evidence, but the provided scientific rationale does not fully support the decision because there is a lack of data on the susceptibility of the older age group (6c). Four reviewers declined to provide comments on charge question 6a, and three declined to provide comments on 6b or 6c. The tiered comments on Charge Question 6 were:

- 1 Tier 1 Recommended Revisions
- 0 Tier 2 Suggested Revisions
- 0 Tier 3 Future Considerations, 1 not tiered comment

#### Tier 1 Recommended Revisions

[underlined: Tier 1 Recommendation 1 of 1]: Panelist recommended: Given that the immune and thyroid effects considered for the chronic RfD were observed after exposure to PFHxS during susceptible lifestages, identical UF values were applied to derive candidate subchronic RfD values (e.g., see Section 5.2.2, p. 5-21 lines 20–27, p. 5-22 lines 3–7). Again, Table 5-6 contains reasoned justifications for the values used for the various UFs in deriving candidate RfDs, and the rationales are also clearly discussed in the text of that section (Derivation of Candidate Lifetime Toxicity Values for the Reference Dose (RfD)). However, Tables ES-1 appears to have the wrong subchronic RfD for immune effects (i.e., 2E−10 mg/kg-day versus 4E−10 mg/kg-day in Table 5-10), which should be corrected.

[underlined: EPA Response]: This has now been corrected to reflect the correct value of 4 × 10^⁻10^ mg/kg-day.

#### Tier 3 Future Considerations

[underlined: Not tiered comment (interpreted as Tier 3)] One panel member commented: “The decision is appropriate based on available scientific evidence. However, the provided scientific rationale does not fully support this decision. This is because there is a lack of data on the susceptibility of the older age group (e.g., ≥60 years old). It is not clear whether the older age group may be more sensitive to children. There is a possibility that the older age group may be more susceptible because of decreased immune function and much longer exposure time (i.e., several decades of exposure).”

[underlined: EPA Response]: EPA considered that there may be different effects by lifestage in the selection of the uncertainty factor for developmental immune effects. “For developmental immune effects in children, a UF_H_ of either 3 or 10 was considered. Specifically, it can be argued that the PODs are derived from susceptible individuals because children’s immune systems are not fully formed and are presumably more sensitive to these effects than most other populations, and thus, the UF_H_ should be reduced (although uncertainty regarding differences across individuals exposed during this sensitive lifestage would still remain). However, a counter argument is that currently there are no data to compare the responses in children with other populations or lifestages, so it is unclear whether these individuals are indeed particularly susceptible to these specific effects. As described in U.S. EPA (2020), other factors, in addition to lifestage, may increase susceptibility, including: demographics, genetic variability, health status, behavior or practices, and social determinants. Ultimately, since the current evidence is insufficient to address these uncertainties, a UF_H_ of 10 is applied for developmental immune effects. For thyroid effects, a UF_H_ of 10 is applied to address differences due to intraspecies variability, including potentially more sensitive or severe effects in susceptible populations or lifestages.”

### G.4.5 Public Comments on Noncancer Toxicity Value Pharmacokinetic Extrapolation and Uncertainty Factors

Related Public comments from AWWA

- “The method for applying DDEFs for rat to human extrapolation are justified. The DDEFs are based on the ratio of the clearance rates (mL/kg/d) estimated across multiple studies in rat and human with central estimates for both rat and human used to calculate the DDEF. For females of reproductive years, it is reasonable to include menstrual loss (as described by Verner and Longnecker 2015) as PFHxS would be excreted along with blood during menstruation.”
- “USEPA provided adequate justification for the uncertainties and explained the decision not to include additional modifications to the adult based clearance values for lifestages. The inclusion of menstrual loss for females of reproductive age (as described by Verner and Longnecker 2015; Lorber et al. 2015) is justified as the increased clearance is estimated based on the volume of blood lost during menstruation. However, the POD was based on ages that did not include the additional clearance as the age (~7 years), so is outside of female reproductive years. In this case, the use of the clearance estimated for males and females outside of reproductive years is acceptable.”
- “the method for applying DDEFs for rat to human extrapolation are justified. The DDEFs are based on the ratio of the clearance rates (mL/kg/d) estimated across multiple studies in rat and human with central estimates for both rat and human used to calculate the DDEF. For females of reproductive years, it is reasonable to include menstrual loss (as described by Verner and Longnecker 2015) as PFHxS would be excreted along with blood during menstruation.”
- “The sex- and lifestage-specific clearance values were based on known differences in clearance between males and females (outside of reproductive years) and is scientifically justified. The inclusion of menstrual loss for females of reproductive age (as described by Verner and Longnecker 2015) is justified as it the increased clearance is estimated based on the volume of blood lost during menstruation.
- “The derivation of the toxicity values appropriately considers potential susceptible populations. The chemical-specific dependence of clearance on sex and lifestage is appropriately considered.
- “the default intra-human variability (UFH = 10) accounts for both pharmacokinetic and pharmacodynamic uncertainty and variability across a population, and is appropriate in this case because the chemical-specific dependence of clearance on sex and lifestage is directly considered. The UFA of 1 for the human based POD is appropriate as there was no animal to human extrapolation required. The use of UFA = 3 for the animal-based PODs is consistent with USEPA guidance, when chemical-specific pharmacokinetics (i.e., the clearance adjustment) is used to derive the HED.”
- “the scientific basis for the use of a UFS = 1 is clearly supported. The developmental period is recognized as a susceptible lifestage for the effects of concern.”

[underlined: EPA Response (to all above related comments)]: No response is necessary.

## G.5 CHARGE QUESTIONS 7 AND 8- CARCINOGENICITY HAZARD IDENTIFICATION AND TOXICITY DERIVATION

7 The Toxicological Review concludes there is inadequate information to assess carcinogenic potential for PFHxS and that this descriptor applies to all routes of human exposure. Please comment on whether the available human, animal and mechanistic studies, and the analysis presented in the Toxicological Review are scientifically justified and clearly described.
8 Given the conclusion there is inadequate information to assess carcinogenic potential for PFHxS, the Toxicological Review does not derive quantitative estimates for cancer effects for oral or inhalation exposures. Is this decision scientifically justified and clearly described?

### G.5.1 Peer Review Comment Summary

Regarding question 7, the majority of the reviewers (8 of 9) agreed that there is inadequate information to assess carcinogenic potential for PFHxS at this time. One reviewer commented that EPA could note determinations for PFAS with similar properties in this document to ensure that “inadequate information” is not confused with “not carcinogenic.” Another reviewer noted that several figures and discussions were missing several of the 12 studies evaluated by EPA. A reviewer commented that there is enough literature about kidney cancer, breast cancer, and liver cancer that these outcomes should be discussed in the document, even if the evidence indicates no association or is insufficient to make a risk determination. This reviewer further noted that wording about the amount and quality of PFHxS cancer studies should be altered.

Regarding question 8, the majority of the reviewers that answered this question (7 of 8) agreed that there is inadequate information to derive quantitative estimates for cancer effects for oral or inhalation exposures to PFHxS at this time. The remaining reviewer agreed with EPA’s conclusion but noted that the cancer section could be improved per his comments to charge question 7. Lastly on reviewer declined to comment on charge question 8.

#### Peer Review Tier Summary for 7

- 3 Tier 1 Recommended Revisions
- 2 Tier 2 Suggested Revisions
- 3 Tier 3 Future Considerations

#### Tier 1 Recommended Revisions

[underlined: Tier 1 Recommendation 1 of 3]: Panelist recommended: Reviewer agrees that there is inadequate information to assess carcinogenic potential for PFHxS at this time. The available studies and analysis presented are scientifically justified and clearly described.

To avoid readers confusing ‘inadequate information’ with ‘not carcinogenic’, recommend that determinations for PFASs with similar properties (e.g., PFOA and PFOS) be noted.

[underlined: EPA Response]: The characterization of the evidence quoted by the panelist above is standard for EPA’s description of evidence integration judgments when the hazard category determined by EPA is “inadequate information.” Please see the ORD Staff Handbook for Developing IRIS Assessments (U.S. EPA, 2022b).

[underlined: Tier 1 Recommendation 2 of 3]: Panelist recommended: Quoting from the document: “the evidence currently available to make a judgment as to whether PFHxS exposure might affect the development of any specific cancers is scant, inconsistent, and limited to low confidence studies.” • Scant is the wrong word. The EPA literature discussion appears to be incomplete. It is ok to reserve judgment if the reason is explained. It is not ok to just say “scant.” The evidence is not limited to low confidence studies. EPA did not mean to say or imply this and should be very sure to remove it. (It is possible to have reservations about outcome decisions without questioning all studies so broadly.) Several of the breast cancer studies are reasonable (and there is no consistent evidence of effect). The NCI kidney cancer work is clearly excellent. These are examples, and not the only potential examples. The outcomes deserve discussion and may show an effect for PFHxS. That is up to EPA to decide. (There are some potential findings for kidney cancer, it is not that clear. It is also potentially consistent with PFOA knowledge, a Hill criteria consideration. Also up to EPA). The Shanghai testicular cancer study is hampered by small numbers (it is not that easy to get pediatric germ cell cancers in substantial numbers) yet is generally reasonable, and shows a strong effect. These are examples.

[underlined: EPA Response]: The summary text on cancer has been updated: “The available evidence for any effect of PFHxS on the risk of developing or dying from cancer is inconsistent. Thus, the available human evidence on breast, thyroid or prostate cancer is considered indeterminate and, overall, based on EPA guidelines (U.S. EPA, 2005), there is inadequate information to assess carcinogenic potential.”

[underlined: Tier 1 Recommendation 3 of 3]: Panelist recommended In Section 3.1.3, it is mentioned that twelve epidemiologic studies were evaluated, but in Figure 3-95, only 11 studies were listed. Similarly. In Section 3.1.3, since twelve epidemiologic studies were evaluated and six were determined to be uninformative, then the remaining six studies should be discussed. However, only five studies were discussed in the paragraph on Pages 3-343 and 3-344. One study is missing in this paragraph. This figure and this paragraph should be updated.

[underlined: EPA Response]: The systematic review identified 12 cancer studies, however, one study (Yeung et al., 2013) was screened as related to hepatocellular carcinoma cancer, but examined the serum and liver concentrations of PFAS, including PFHxS, among patients who had liver transplants − some of whom had hepatocellular carcinoma cancer; this study did not assess cancer risk and was not evaluated for study quality. Since this study was not actually about cancer risk, it was not included in the heat map. A footnote has been added for clarification. The remaining five cancer studies were discussed.

#### Tier 2 Suggested Revisions

[underlined: Tier 2 Suggested revisions 1 of 2]: Panel Member Suggested Revision there are missing topics in the discussion, and it would improve confidence to address them. Of these kidney cancer and breast cancer have has the most evidence for PFHxS. Breast cancer is consistently null. Kidney cancer is worrisome as for other PFAS. There is enough about liver cancer that it should probably be discussed. A listing is provided.

Breast cancer: In a Chinese case-control study of 373 cases and 657 controls, PFOA was associated with certain subtypes and PFHxS was not associated (Li et al., 2022).

- In the longitudinal Dongfeng-Tongji cohort, showed total PFAS and PFHpA associations with breast cancer, but not for PFHxS (Feng et al., 2022).
- A large case-control study in Japan found no evidence for association of PFHxS or any PFAS with breast cancer. Some inverse associations were noted (Itoh et al., 2021).
- PFAS including PFHxS were not positively associated with breast cancer in the California Teacher’s study (Hurley et al., 2018).
- A meta-analysis did find a relationship for PFOA and PFHxS (Jiang et al., 2022), but please note additional findings below from studies after the closure date for the EPA review.

Kidney cancer: The important NCI study by (Shearer et al., 2020) found an association of PFAS, PFOA, PFOS and PFHxS (OR = 2.07, 95% CI: = 1.06 to 4.04; P trend = .04) to kidney cancer. A doubling of PFHxS was associated with OR continuous of 1.27 (95% CI: = 1.03 to 1.56; P = .02). Highest vs. lowest quartile was (OR = 2.07, 95% CI: = 1.06 to 4.04; P trend = .04).

Kidney cancer: Pre-diagnostic serum PFHxS was not associated with kidney cancer in the PLCO cancer screening trial including NCI authors (Rhee et al., 2023). Multiple cancers including Kidney Cancer: The Ronneby cohort assessment found no associations of PFHxS and PFOS exposure to cancers, with the possible exception of kidney cancer (Li et al., 2021). Liver cancer: In a small case control study, PFHxS was higher in cases but statistical significance was only for PFOS (Goodrich et al., 2022). Several PFAS were higher in a medium-sized (203 cases and controls) liver cancer study in the Zhejiang hospital records (Hangzhou, China), including PFHxS, but only PFOS and 6:2 Cl-PFESA reached statistical significance. For PFHxS OR was 1.191 (95% CI: 0.903, 1.479) (Cao et al., 2022). Testicular cancer: A small case control study of pediatric testicular germ cell tumors in Shanghai found the odds ratio for a 1 ng/L increase in PFHxS was 19.47 (95% CI: 4.20–90.26) (Lion et al., 2020). Note that there is also an adult testicular cancer study addressing PFHxS after the review closure date (see below)

[underlined: EPA Response]: The reviewer identified 11 cancer studies for consideration. Appendix B.3 (lit update) already captured 4 of these studies. The remainder were added to Appendix B.3. In summary, the available epidemiologic evidence on PFHxS and the risk of cancer remains inadequate; the newly identified studies are not impactful because there were limited numbers of studies for any one cancer type except for breast cancer, however those results were inconsistent with studies showing increased risks, decreased risks and no risks.

[underlined: Tier 2 Suggested revisions 2 of 2]: Panel Member Suggested Revision The article concerning pediatric germ cell tumors Lin et al., 2020 could prompt consideration of prenatal or early life exposure and testicular germ cell cancer.

[underlined: EPA Response]: Lin et al. (2020) reported a very strong effect [The odds ratio for a 1 ng/L increase in PFHxS was OR = 19.47 (95% CI: 4.20–90.26)] but was based on 42 cases and 42 controls and included 6 covariates in the regression. Such an analysis would likely stretch the data so far that the model breaks down. For a different PFAS fit using the same covariates, Perfluorooctanesulfonamide (PFOSA), the OR = 3404.13; 95% CI: 0.04, 2.69 × 10^8^) which reveals that model is highly unstable and critically deficient. Therefore, the results for PFHxS from this model cannot be taken at face value.

#### Tier 3 Future Considerations

[underlined: Tier 3 Future considerations 1 of 3] Panel member commented: There are important new cancer studies which are relevant but possibly too late for consideration. It is up to EPA if additional work is justified: Blood cancer/ALL The NCI study about acute lymphoblastic leukemia (ALL) found associations to other PFAS, but not to PFHxS (Jones et al., 2023) (childhood). The LifeLink Cohort longitudinal study found an association between PFHxS doubling and incident HR 1.34 (95% CI: 1.02,1.75) for chronic lymphocytic leukemia/small cell leukemia and no others among cancers investigated Winquist et al., 2023. Brain cancer: The OR per ln-unit increase in PFHxS was 8.16 (95% C.I 2.98–68.89) for brain cancer in NHANES data (Moon et al., 2024). In addition, PFHxS was not associated with esophageal cancer or prostate cancer, but other PFAS were associated with those outcomes in this study. Breast cancer: a systematic view and meta-analysis did not find an association of PFAS to breast cancer, including PFHxS (Cong et al., 2023). However, this finding was not consistent with an earlier review and meta-analysis, which did find a relationship for PFOA and PFHxS [Jiang et al., 2022]. Melanoma: In NHANES data, The OR of melanoma for one unit increase of ln (PFHxS) was 1.55 (95 % CI 1.07–2.25) Moon et al., 2024. Prostate cancer: In a large prospective study, NCI authors did not find a relationship of PFHxS or any PFAS to prostate cancer (Rhee et al., 2023). Testicular cancer: PFOS but not PFHxS was associated with testicular cancer in a longitudinal nested case-control study from NCI in US Air Force servicemen (Purdue et al., 2023). Thyroid cancer: A strong case control study nested in a longitudinal study design found no relationship between PFHxS and thyroid cancer. (There were some suggestions for subclassification associations for other PFAS) (Madrigal et al., 2024). A small case control study found evidence of PFOS (and especially n-PFOS) to thyroid cancer, but PFHxS was not associated (van Gerwen et al., 2023). A Chinese case-control study matched on sex and age found no associations of PFAS including PFHxS to thyroid cancer (Li et al., 2023).

A US geographic ecologic study of water contamination levels suggested that PFOA and PFNA but not PFHxS was linked to thyroid cancer Alsen et al., 2023.

Experimental cancer studies:

Liver cancer: Sim et al., 2023 found experimental evidence of proliferation effects on HepB, cells. A nice review of relevant mechanisms is Boyd et al., 2022.

[underlined: EPA Response]: The reviewer identified 14 additional cancer studies for consideration. Two studies did not meet PECO (Boyd et al., 2022) (Review) and (Cong et al., 2023) (meta-analysis). The remainder were added to Appendix B.3. In summary, the available epidemiologic evidence on PFHxS and the risk of cancer remains inadequate; the newly identified studies are not impactful because there were limited numbers of studies for any one cancer type except for breast cancer, however those results were inconsistent with studies showing increased risks, decreased risks and no risks.

[underlined: Tier 3 Future considerations 2 of 3] Panel member commented: There is reason to separately consider the childhood, adolescent, and early adult (the major peak), and late adult (the more gradual peak for the population) testicular cancers. This will create small number issues, but the effort could be instructive. Funding could definitely be directed at the possibility of PFAS relationships to childhood testicular cancers, which are rare and have different cell types. It would not be hard to create a separate consideration for adolescent and young adult testicular cancers from late adult testicular cancers in existing studies, and EPA could play a role in encouraging that kind of work.

[underlined: EPA Response]: EPA acknowledges the utility of this type of information, which is lacking in the currently available evidence base; however the IRIS Program does not conduct experimental studies.

[underlined: Tier 3 Future considerations 3 of 3] Panel member commented: Since there is a lack of animal studies on carcinogenicity of PFHxS in animals and since PFHxS is really a very important environmental contaminant, it is recommended to conduct a two-year cancer bioassay study of PFHxS in two animal species following EMA (2022), FDA (2006), OECD (2018), or EPA (2005) guidelines.

[underlined: EPA Response]: EPA acknowledges the utility of this type of information, which is lacking in the currently available evidence base; however, the IRIS Program does not conduct experimental studies.

#### Peer Review Tier Summary for 8

- 0 Tier 1 Recommended Revisions
- 1 Tier 2 Suggested Revisions
- 0 Tier 3 Future Considerations

#### Tier 2 Suggested Revisions

[underlined: Tier 2 Suggested revisions 1 of 1]: Panel Member Suggested Revision Reviewer agreed that EPA’s conclusion seems reasonable in many cases; “Nevertheless, please see comments in charge question 7 about improving the cancer section and reviewing the literature with specific suggestions for areas of focus, including kidney cancer, testicular cancer (strong study with null results), and childhood cancer.

[underlined: EPA Response]: Please see responses to Tier 2 charge question 7 and 1 of 3 tier 3 question 7.

### G.5.2 Public Comments on Carcinogenicity Hazard Identification and Toxicity Derivation Related Public comments from AWWA

- The evaluation in the Toxicological Review clearly supports a conclusion that there is not adequate animal, human or mechanistic information to support an assessment of carcinogenic potential for PFHxS. The USEPA (2023a) evaluated 12 epidemiological studies of cancer and found that 6 were uninformative and 6 were of low confidence. The USEPA (2023a) described the evidence as indeterminate for breast, thyroid, or prostate cancer because the epidemiological studies have issues related to when exposure was measured in relation to the diagnosed cancer (the etiologically relevant window of exposure for solid tumors is generally 15–40 years before cancer diagnosis), selection bias, and potential confounding. There were no animal studies of carcinogenicity identified by the USEPA.”
- It is not possible or appropriate to derive a quantitative estimate for cancer effects since there is a complete lack of adequate dose-response information.

[underlined: EPA Response (to all above comments)]: No response is necessary.

14 For the decreased antibody responses, Selgrade (Tox Sci 2007;100:328–332) suggests that these specific immunotoxic effects may be broadly indicative of developmental immunosuppression impacting these children’s ability to protect against a range of immune hazards.