# APPENDIX E DETAILED PHARMACOKINETIC ANALYSES

This appendix provides two detailed pharmacokinetic analyses. The first is a Bayesian analysis of perfluorohexanesulfonic acid (PFHxS) pharmacokinetics in laboratory animals to estimate key pharmacokinetic parameters. The second is the description and evaluation of a one-compartment pharmacokinetic (PK) modeling approach for estimating internal doses, evaluated against rat PFHxS PK data using the mean parameter values estimated for male rats in the Bayesian estimation.

## E.1 BAYESIAN ANALYSIS OF PFHxS PHARMACOKINETICS IN RATS, MICE, AND MONKEYS

We estimated the sex-specific pharmacokinetic parameters (half-life, volume of distribution, and clearance) of PFHxS in rats, mice, and nonhuman primates (cynomolgus monkeys) by fitting one- and two-compartment models to the available concentration versus time data. A Bayesian hierarchical methodology was developed to fit these models because of the need to pool time-course concentration data across numerous studies with varying exposure scenarios within each study. This approach allowed for each concentration-versus-time data set to be fit to each model with dataset-specific parameters sampled from a population-level distribution that models the similarities between each data set. In addition, the Bayesian analysis allowed for the generation of central estimates and credible intervals for the pharmacokinetic parameter of interest (e.g., half-life, volume of distribution and clearance) using posterior distributions from the estimated variables. Finally, the Bayesian methodology allowed for hypothesis testing of the one- and two-compartment formulations to decide which model more appropriately fit the data.

### E.1.1 Pharmacokinetic Model

To determine pharmacokinetic parameters for PFHxS, we estimated constants for both one- and two-compartment model assumptions. For a one-compartment model assumption, the following exponential decay functions were fit to the available data:

C_1 − c m p t_^I V^ (t) = (D)/(V) e^− k_e_ t^ (E-1)

C_1 − c m p t_^o r a l^ (t) = (D)/(V) ((k_a_)/(k_a_ − k_e_)) (e^− k_e_ t^ − e^− k_a_^) (E-2)

where D represents the administered dose and V, k_e_, and k_a_ represent the central compartment volume, elimination constant, and absorption constant (for oral only) to be fit. From these fitted constants, pharmacokinetic parameters are derived:

V_d_ = (V)/(B W) (E-3)

t_(1)/(2)_ = (ln 2)/(k_e_) (E-4)

C L C = V_d_ ∗ k_e_ (E-5)

where V_d_, t_1/2_, and CLC represent the volume of distribution, terminal half-life, and clearance respectively and BW represents the animal body weight. Using the equations above, we fit CLC, V_d_, and k_a_ (for oral exposure) to the available time-course in vivo animal data.

For the two-compartment model assumption, the following exponential decay functions were fit to available data

A^I V^ = (α − k_d c_)/(α − β) ; A^o r a l^ = k_a_ ((k_d c_ − α)/((k_a_ − α) (β − α))) (E-6)

B^I V^ = (β − k_d c_)/(β − α) ; B^o r a l^ = k_a_ ((k_d c_ − β)/((k_a_ − β) (α − β))) (E-7)

C_2 − c m p t_^I V^ (t) = (D)/(V) (A^I V^ e^− α t^ + B^I V^ e^− β t^) (E-8)

C_2 − c m p t_^o r a l^ (t) = (D)/(V) (A^o r a l^ e^− α t^ + B^o r a l^ e^− β t^ − (A^o r a l^ + B^o r a l^) e^− k_a_ t^) (E-9)

where D represents the administered dose and V, α, β, k_dc_, and k_a_ represent central compartment volume, alpha-phase elimination constant, beta-phase elimination constant, deep-to-central compartment rate constant, and absorption constant (for oral only) to be fit. From these fitted constants, the remaining two-compartment constants (k_cd_: central-to-deep compartment rate constant and k_e_: elimination constant) and the deep compartment volume (V_deep_) are derived by solving:

α + β = k_c d_ + k_d c_ + k_e_ (E-10)

α ∗ β = k_d c_ ∗ k_e_ (E-11)

V_d e e p_ = V (k_c d_)/(k_d c_) (E-12)

R = (k_d c_)/(k_c d_) = (V)/(V_d e e p_) (E-13)

which allows for the desired pharmacokinetic parameters to be derived using the following equations:

V_d − s s_ = (V + V_d e e p_)/(B W) = (V)/(B W) ((k_c d_ + k_d c_)/(k_d c_)) (E-14)

t_(1)/(2)_ = (ln 2)/(β) (E-15)

C L C = (V)/(B W) ∗ k_e_ (E-16)

where V_d-ss_, t_1/2_, and CLC represent the steady-state volume of distribution, terminal half-life, and clearance respectively and BW represents the animal body weight. Using the equations above, we fit CLC, V_d_, and k_a_ (for oral exposure) to the available time-course in vivo animal data.

#### Bayesian Inference

The fitted constants for each model structure (described above) were determined using available time-course concentration data reported in mice, rats, and non-human primates with the parameters for each model estimated using a Bayesian calibration approach. As described in the main text, owing to the discrepancy between oral and IV dosing bioavailability, only mice and rat time-course concentration data following oral gavage dosing was used for rodent-specific fits, while only IV dosing was available for nonhuman primate fits. In addition, for mice and nonhuman primates, time-course data from only one study (Sundström et al., 2012) were available and all dose-specific data were pooled into a single data set and fit to the one- and two-compartment models described above. However, a hierarchical Bayesian calibration approach was used to fit the observed time-course concentration data for male and female rats using data reported from multiple studies (Kim et al., 2016; Kim et al., 2018b; Huang et al., 2019b). We reparametrized the two-compartment model described above in terms of CLC and V_d−ss_ to allow for parameter identifiability. This ensures that that α > β and ensures the exponential terms are identifiable and do not “flip” while exploring the parameter space during Markov-chain Monte-Carlo (MCMC) sampling. For oral doses, the absorption rate (k_a_) was assumed to be rapid with an absorption half-life less than 1 hour (ATSDR, 2021). With the exception of k_a_, priors for each pharmacokinetic parameter were chosen to be “weakly informative” based on prior knowledge of PFAS pharmacokinetics (ATSDR, 2021) with 95% equal-tailed intervals spanning multiple order of magnitude. Finally, model priors for the two-compartment parameters (k_12_ and R) were chosen such that k_cd_ ≪ 1 and R ≫ 1. These priors for a two-compartment model mimic the behavior of a one-compartment model, ensuring that true two-compartment model behavior is only exhibited when strongly driven by the observed data.

Priors for pharmacokinetic parameters are presented in Table E-1 with corresponding model-specific parameter prior distributions presented below. Finally, a sensitivity analysis on the model priors is shown in the Prior Sensitivity Analysis section.

Table E-1 Weakly informed prior distributions for pharmacokinetic parameters used in the Bayesian analysis

| Median | Eti_3% | Eti_97%
Half-life (d) | 2.5 | 0.008 | 828
Clearance (mL/kg-d) | 60 | 0.39 | 9273
V_d-ss_ (mL/kg) | 222 | 13.2 | 3729

Median, lower (eti_3%), and upper (eti_97%) of the equal-tailed interval prior for each pharmacokinetic parameter.

For the mouse and nonhuman primate data, the following model was implemented to fit all data reported in Sundström et al. (2012):

ln k_a_ ∼ N (ln 81 , 0.25) (E-17)

ln C L C ∼ N (ln 0.06 , 2.68) (E-18)

ln V_d − s s_ ∼ N (ln 0.22 , 1.5) (E-19)

ln R ∼ N (ln 100 , 1.5) t w o c o m p a r t m e n t m o d e l (E-20)

ln k_c d_ ∼ N (ln 0.01 , 1.5) t w o c o m p a r t m e n t m o d e l (E-21)

C_i_ = {C_1 − c m p t_^r o u t e^ for 1-compartment model, C_2 − c m p t_^r o u t e^ for 2-compartment model (E-22)

σˇ ∼ E x p (1) (E-23)

C_i_ ∼ L N (x¯_i_ , σ˜) (E-24)

where x̅_i_ is the sample mean of the observed concentrations at time t_i_ for all times reported. Model parameter priors are derived from the pharmacokinetic parameter priors defined earlier.

For the hierarchical approach, the concentration versus time data comprised a population- and data set-level for which model parameters were estimated. Here, each data set represented each study/sex/dose concentration versus time data set extracted from the literature and were fit using the model:

C_i j_ = {C_1 − c m p t_^r o u t e^ for 1-compartment model, C_2 − c m p t_^r o u t e^ for 2-compartment model (E-25)

C_i k_ ∼ L N (x¯_i j_ , σ˜_k_) (E-26)

where x̅_ij_ is the sample mean of the observed concentrations at time t_ij_ for data set j and σ˜_k_ is study-level log-transformed standard deviation for the relative errors based on study k. Study-level priors for σ˜_k_ were determined using the average log-transformed standard deviations:

σ¯_i , j_^2^ = ln (1 + (s_i , j_^2^)/(x¯_i , j_^2^)) (E-27)

γ_k_ = (∑_i_ σ¯_i , j ∈ k_)/(n_k_) (E-28)

where s_i,j_ is the sample standard deviation on the observed concentrations at time t_i,j_ for study k. If s_ij_ was available, σ˜_i , j_ is the log-transformed standard deviation using the sample mean and standard deviation. For studies in which sample standard deviations could not be extracted, an average of all log-transformed standard deviations was used, which allowed for study-level prior distributions on the error model log-transformed standard deviation:

σ˜_k_ ∼ {Exp ((1)/(γ_k_)) if γ_k_ available, Exp ((1)/(γ)) otherwise. (E-29)

Using this model, data set-level fitted constants were assigned priors based on a noncentered parameterization of a population-level distribution. This reparameterization of a typical hierarchical Bayesian model allows for increased sampling efficiency and can be more efficient for sampling when there is limited data (Betancourt and Girolami, 2013). Finally, nonelimination rate constants (k_a_ and k_dc_) were assigned a unit normal, weakly informative prior to aid parameter identifiability (Gelman et al., 2015):

ln μ_k_a__ ∼ N (ln 81 , 0.25) (E-30)

ln μ_V_d − s s__ ∼ N (ln 0.22 , 1.5) (E-31)

ln μ_R_ ∼ N (ln 100 , 1.5) t w o c o m p a r t m e n t m o d e l (E-32)

ln μ_k_c d__ ∼ N (ln 0.01 , 1.5) t w o c o m p a r t m e n t m o d e l (E-33)

ln μ_C L C_ ∼ N (ln 0.06 , 2.68) (E-34)

σ_k_a_ , V , k_e_ , α , β , k_d c__ ∼ Exp (1) (E-35)

ln (k_a_ , V , k_e_ , α , β , k_d c_)_j_ ∼ N (μ_k_a_ , V , k_e_ , α , β , k_d c__ , σ_k_a_ , V , k_e_ , α , β , k_d c__) (E-36)

For both the single-level and hierarchical approaches, one- and two-compartment model goodness of fits were compared using the leave-one-out cross-validation (LOO-CV) method for pointwise out-of-sample prediction accuracy (LOO, (Yao et al., 2017)). Pharmacokinetic parameters from the most appropriate model, as judged by the LOO comparison, were reported. To estimate the resulting pharmacokinetic parameters, we examined posterior probability densities of the parameters from the LOO-determined model and calculated distributional estimates of the half-life, volume of distribution, and clearance using the equations described above. The parameter space was sampled using PyMC (Salvatier et al., 2016) using four independent Markov chains run for 10,000 iterations per chain. Posterior parameter distributions were determined using the final 5,000 iterations of each chain ensuring an effective sample size (ESS) greater than 10,000 (Kruschke, 2021). Convergence was assessed using a potential scale reduction factor with a maximum threshold of R^ = 1.05 (Kruschke, 2021).

#### Prior Sensitivity Analysis

To investigate the impact of prior selection on posterior pharmacokinetic parameter estimation, we conducted a sensitivity analysis on the priors used in the Bayesian analysis. This sensitivity analysis modified the population mean and population variance priors for clearance and volume of distribution to determine how increasing uncertainty in the prior impacted the resulting posterior. Priors were classified into three categories: weakly informed, uninformed mean, and uninformed variance. Weakly informed priors are defined using the half-life, clearance, and volume of distribution described above. Using these priors an example of a prior predictive check on a subset of data is shown below which demonstrates that the available data for fitting fall within the prior 94% credible interval.

Figure E-1 Prior predictive check to ensure equal-tailed interval from prior distributions encompass the available time-course concentration data for fitting

Observed data from Huang et al. (2019b).

Uninformed population mean priors used ln μ_CLC_~N(0, 5) and ln μ_V_d−ss__~N(0,5) while uninformed population variance priors increased the scale factor of the population standard deviation on the clearance and volume of distribution from Half Normal(0.5) (default) to Half Normal(3) to allow for increased heterogeneity in dataset-to-dataset means. The following table compares these three classes of priors and their impact on the posterior pharmacokinetic parameter distributions.

Table E-2 Posterior distribution results from prior sensitivity analysis for the three classes of priors (weakly informed, broad, and uninformed)

For each pharmacokinetic parameters, mean, standard deviation (SD), lower HDI (HDI 5%), and upper HDI (95%) are presented.

Prior | Half-life (d) | | | Clearance (mL/kg-d) | | | V_d-ss_ (mL/kg)
| Mean | SD | HDI 5%, 95% | Mean | SD | HDI 5%, 95% | Mean | SD | HDI 5%, 95%
Weakly informed (default) | 1.86 | 0.41 | 1. 21, 2.48 | 85.6 | 16.1 | 61.2, 110 | 222.3 | 27.7 | 176.9, 263.8
Uniformed population mean | 1.85 | 0.41 | 1.19, 2.47 | 86 | 16.2 | 61.5, 110.5 | 222.5 | 28 | 178.2, 265.6
Uninformed population variance | 1.87 | 0.52 | 1.11, 2.60 | 86.3 | 22.4 | 56.3, 114.2 | 222.4 | 31.1 | 173.7, 268.9

Finally, differences in posterior distributions for these three pharmacokinetic parameters is visualized by plotting the cumulative distribution of the three choices of prior.

Figure E-2 Cumulative posterior distribution for the weakly informed (red), uninformed population mean (blue), and uninformed population variance (green) priors

Dashed lines represent the lower (3rd percentile) and upper (97th percentile) comprised the 94% credible interval (CI).

From Figure E 2, weakly informed and broad population means completely overlap demonstrating no impact on prior choice for the population mean. Comparatively, the uninformed variance slightly increases the width of the 94% CI. for the PK parameters of interest while leaving the central estimates unchanged. Informed by these findings, EPA used the weakly informed pharmacokinetic priors for fitting available time-course concentration data.

#### Hamiltonian Monte-Carlo convergence

We used the No-U-Turn Sampler (NUTS) algorithm as the Hamiltonian Monte Carlo (HMC) for parameter estimation. Therefore, three convergence criteria were assessed before using a model: no divergences transitions when sampling the posterior distribution, a potential scale reduction factor (Ȓ < 1.05) to ensure proper chain mixing, and an effective sample size (ESS > 100 per chain) for reliable Ȓ calculation. All three criteria must be passed before a model is considered. Below are the posterior traces of the PFHxS pharmacokinetic model parameters (Ȓ and ESS values are available in accompanying notebook where Ȓ < 1.01 is shown for all model parameters) to visually demonstrate the posterior distributions.

Figure E-3 Traceplots for population pharmacokinetic parameters for mouse posterior distributions

Left: Male (1-compartment); Right: Female (1-compartment).

Figure E-4 Traceplots for population pharmacokinetic parameters for rat posterior distributions

Left: Male (1-compartment); Right: Female (2-compartment).

Figure E-5 Traceplots for population pharmacokinetic parameters for non-human primate posterior distributions

Left: Male (2-compartment); Right: Female (2-compartment).

#### Summary of study-specific clearance values and model fits

Using prior knowledge of PFAS pharmacokinetics, coupled with a multiple PFHxS time-course concentration datasets, species- and sex-specific pharmacokinetic parameters such as clearance, volume of distribution, and half-life were determined for mice, rats, and non-human primates. Table 3-6 has a complete summary of the PK parameters (Bayesian parameter means and CIs for clearance, Vd, and half-life) for each species and sex. Prior knowledge is also used in fitting the functional form of each pharmacokinetic model to determine which model is most appropriate for the given species and sex. In this analysis, the two-compartment priors for R ≫ 1 and k_cd_ ≪ 1 result in one-compartment model behavior. This ensures that the observed data (likelihood) must be strong enough to move the model towards two-compartment (biphasic) behavior. Using these priors, female rat along with male and female primates utilized a two-compartment model while male rats and male/female mice resulted in a one-compartment fit as judged by the LOO-CV and visual inspection. Two-compartment fits showed a clear distribution and excretion phase while one-compartment fits demonstrated single-phase elimination.

As described above, three data sets were used for the female rat-specific parameter estimation for which only the oral gavage data were used for fitting (Kim et al., 2016; Kim et al., 2018b; Huang et al., 2019b). In addition to these three, a fourth data set (Benskin et al., 2009) was used for male rats. The sex-specific clearance value distribution obtained from fitting the three data sets together had means and 90% credible intervals of 85.3 (59.7 – 108) mL/kg-day in female rats and 5.46 (3.87 – 6.97) mL/kg-day in male rats. Comparatively, sex-specific clearances in mice, determined from Sundström et al. (2012), had means and 90% credible intervals of 3.81 (3.54–4.07) mL/kg-day in female mice and 3.14 (2.98–3.29) mL/kg-day in male mice. Resulting pharmacokinetic parameters from Sundström et al. (2012) had means and 90% credible intervals of 2.1 (1.78–2.42) mL/kg-day in female cynomolgus monkeys and 1.17 (0.72–1.64) mL/kg-day in male cynomolgus monkeys. Visual inspection male and female fits across mice, rats, and non-human primates can be investigated below.

Figure E-6 Predicted (black line with blue 90% credible interval) and observed (black circles) serum time-courses for male (top panel) and female (bottom panel) rats after a 4 mg/kg gavage PFHxS

Observed data from Kim et al. (2016).

Figure E-7 Predicted (black line with blue 90% credible interval) and observed (black circles) serum time-courses for male (top panel) and female (bottom two panels) rats after a 10 mg/kg gavage (both male and female) and 4 mg/kg gavage (female only) PFHxS

Data from Kim et al. (2018b).

Figure E-8 Predicted (black line with blue 90% credible interval) and observed (black circles) serum time-courses for male (top panel) and female (bottom panel) rats after a 4, 16, or 32 mg/kg gavage PFHxS

Data from Huang et al. (2019b).

Figure E-9 Predicted (black line with blue 90% credible interval) and observed (black circles) serum time-courses for male (top panel) and female (bottom panel) mice after a 1 or 20 mg/kg gavage PFHxS

Data from Sundström et al. (2012).

Figure E-10 Predicted (black line with blue 90% credible interval) and observed (black circles) serum time-courses for male (top panel) and female (bottom panel) nonhuman primates following a 10 mg/kg IV PFHxS dose

Data from Sundström et al. (2012).

## E.2 DESCRIPTION AND EVALUATION OF A CLASSICAL PK APPROACH

One- or two-compartment classical PK models were evaluated, where the second, deep-tissue compartment is inactive when the corresponding parameters are set to zero. The PK model was implemented using the MCSim language and compiled for use with corresponding tools. Specific simulations and other analysis were conducting using R software. A package of the R/MCSim files and supplementary input data used to perform the following analyses, including a README document describing each file and R functions defined therein, is available (Schlosser, 2024). The corresponding differential equations for the amount of a substance in an individual after oral dosing is:

dA_c_ / dt = F_abs_ × dose × BW − CL × r_m : mf_ × A_c_ / V_c_ − k_12_ × A_c_ + k_21_ × A_t_ and (E-37)

dA_t_ / dt = k_12_ × A_c_ − k_21_ × A_t_ , (E-38)

where A_C_ and A_t_ are the amounts in the individual’s central (c) and tissue (t) compartments, (mg), F_abs_ is the fraction absorbed for an oral dose (bioavailability), dose is the (mg/kg-day) exposure, BW the body weight (kg), CL is the clearance (L/kg-day), V_c_ is the volume of distribution for the central compartment (L/kg), r_m:mf_ is a factor to account for nonuniform distribution between a pregnant individual and her fetus(es), in the event that one wishes to simulate dosimetry during gestation, and k_12_ and k_21_ are the rate constants for transfer from the central to tissue and tissue to central compartments, respectively (d^⁻1^) (with k_12_ set to zero for a one-compartment model). For the following simulations of dosimetry in nonpregnant animals r_m:mf_ is set to 1. While data are not available to indicate that distribution differs in pregnancy versus nonpregnant adult animals, the term is still included to allow for this possibility. For this analysis CL and V_c_ are assumed to be constant at the values determined from PK studies in young adult animals, as described above. The concentration in an individual’s blood is then C = A_c_∙r_m:mf_/(V_c_∙BW).

The changes in male and female rat BW observed in the NTP bioassay (28-day exposure (NTP, 2019)) are shown in Figure E-11. Internal doses of PFHxS predicted by the PK model as a function of exposure day, using the population mean male rat parameters from Table 3-1 and Table 3-3, are shown in Figure E-12. The dose is assumed to be adjusted for changes in BW each day. Because the animals were necropsied on day 29, 1 day after the final dose, the model simulations include a final day with zero exposure. Mean plasma PFHxS concentrations from the NTP study, collected at time of necropsy, are shown for comparison. Very little accumulation was predicted in female rats after exposure day 10, whereas male rats accumulated PFHxS throughout the study. The steady state concentrations at the lowest non-zero doses (calculated algebraically) are also shown for comparison, clearly demonstrating that the female simulations reach steady-state while the males do not.

Figure E-11 Male and female rat body weight changes during 28-day PFHxS bioassay

Data sets from NTP (2019) are identified by the dose (mg/kg-d).

Figure E-12 Predicted accumulation and observed end-of-study of PFHxS in male rats as a function of dose

The plasma concentrations, observed in the NTP (2019) bioassay, were measured one day after the final dose, hence are plotted on day 29. Exposure is treated as continuous for 28 days. The horizontal, grey dashed line is the estimated steady-state concentration for a 0.625 mg/kg-d dose in males and a 3.12 mg/kg-d dose in females, i.e., the lowest non-zero exposure level for each sex.

The y-axis scales in Figure E-12 are set to focus primarily on the range of the experimental data and because of nonlinearity in that data (discussed in more detail in the Pharmacokinetics section) the upper portions of the higher concentration curves from the PK model are outside that range. For example, when the dose to male rats was increased from 5 to 10 mg/kg-d, the resulting mean plasma concentrations only increased from 162 to 198 mg/L, or 22%. This nonlinearity was suggested by the PK data, described in the introduction to this Pharmacokinetics section, for which clearance appeared to be higher at higher administered doses in rats, although the difference in the PK parameters may not have been statistically significant. Because the PK model evaluated is based on first-order kinetics, it predicts that the plasma concentration doubles when the dose is doubled. A likely mechanism for the observed nonlinearity is saturable renal resorption, allowing for faster elimination of PFHxS at higher internal concentrations. It is also possible that absorption is less efficient at higher dose levels. While the linear PK model is thereby shown to provide what may be considered acceptable predictions of internal dose at lower exposures, the results are inadequate for 2.5 mg/kg-d and higher in male rats and for 12.5 mg/kg-d and higher in female rats, and the overall performance of the model is poor.

Further insight into the determinants of model predictions is provided by a sensitivity, specifically evaluating the impact of variation in each parameter on the predicted end-of-study plasma concentration. Each parameter was increased separately by 1% and the normalized sensitivity coefficient (SC) calculated as:

SC (p_i_) = 100^∗^ (C (p_i_ × 1.01) / C (p_i_) − 1) , (E-40)

where C(p_i_) is the plasma concentration with parameter p_i_ unchanged and C(p_i_×1.01) is the plasma concentration with p_i_ increased by 1% (keeping all other parameters unchanged). For male rats, the clearance had only a modest influence with SC(CL) = −0.34 while the volume of distribution significantly determined the predicted result with SC(Vd) = −0.66. The negative values indicate that increases in either parameter decrease the predicted plasma concentration, as expected, but because CL is low and the males are still accumulating PFHxS at 29 days, the Vd was the primary factor. For female rats, the relative role of the two parameters for day 29 plasma concentration is effectively reversed, with SC(CL) = −1.4 and SC(Vd) = 0.4. This result for CL reflects the fact that the steady-state concentration, i.e., the concentration on day 28, is determined by CL (C(steady-state) = dose/CL), while the modest [underlined: positive] sensitivity to Vd reflects the fact that the extent of decline in concentration between day 28 and day 29 is reduced when Vd is larger because the total amount in the animal at steady state (on day 28) increases with Vd. When the total amount in the animal on day 28 is higher, the clearance of a given quantity over the following day has a lower proportionate effect on the amount remaining on day 29. For both males and females, the concentration is proportional to the faction absorbed, SC(F_abs_) = 1, which is not surprising, while there was minimal sensitivity to the deep tissue distribution parameters in female rats, with |SC(k_12_)| = |SC(k_21_)| = 0.01. Hence, while inclusion of the deep tissue compartment may have resulted in a statistically significant improvement in model fit to the calibration data for female rats, it has little impact on the predicted concentration after 28 days of dosing.

While the PK model is not very accurate, the results provide a qualitative picture of how PFHxS accumulates in male vs. female rats at low doses where the predictions are within 2-fold of the data. Specifically, in male rats the model predicts a steady accumulation over the 28 days of exposure, that may be reasonably approximated as a linear increase in blood concentration over time. Given a linear increase, the average concentration in male rats in this dose range is expected to simply be one half of the concentration measured on the final day. To estimate the internal dose at exposures different from those evaluated in the NTP study (i.e., identified from dose-response modeling), a linear interpolation between the measured final doses can be performed.

On the other hand, female rats are predicted to reach steady state by day 10 in which case the measured final concentration provides a reasonably good estimate of the average concentration in the females during the study. As with the males, to estimate the final concentration for doses other than those evaluated in the NTP study, a linear interpolation between the measured concentrations can be used.

Pharmacokinetic Modeling Summary

Predictions of the two-compartment PK model using mean parameters for male and female rats from the Bayesian analysis described in E.1 were compared to measured serum concentrations at the end of the NTP 28-day bioassay (Figure E-12). While the predictions were within a generally acceptable range (i.e., 2-fold) of the data at the two lowest doses the model did not predict the higher dose data well. Even at the lowest doses the inability of the model to capture the nonlinearity in serum concentration vs. dose shown by the data. On the other hand, the model predictions suggest a qualitative conclusion that there is a steady accumulation in male rats during the bioassay (i.e., with serum concentrations increasing linearly with time) while in female rats, steady-state is achieved fairly quickly.

Given these qualitative features of the PK for male and female rats, the NTP data can be algebraically interpolated to estimate internal doses during the bioassay without use of the PK model. Specifically, one can assume that in female rats the average serum concentration during the bioassay is equal to the final observed concentration and linear interpolation can be used to estimate that serum concentration at doses between those observed. In male rats the average serum concentration is predicted to be one-half of the final observed concentration and linear interpolation can also be used to estimate the final serum concentration at doses between those observed.

Finally, given the PK model’s inability to accurately predict dosimetry in the NTP bioassay, extrapolation of the model to a multi-generational bioassay for which there are no measured serum concentrations available for validation is not recommended. Further, in the absence of measured serum concentrations the internal dose cannot be estimated by interpolation. Therefore, the best option for extrapolation of rat muti-generational bioassay data is to assume that serum concentrations in the rats reach steady-state, in which case a data-derived extrapolation factor (DDEF) can be used to estimate the human equivalent dose for a given point-of-departure dose.