# APPENDIX D BENCHMARK DOSE MODELING RESULTS

## D.1 BENCHMARK DOSE MODELING SUMMARY FOR NONCANCER ENDPOINTS

### D.1.1 Benchmark Dose Modeling Approaches

The endpoints selected for benchmark dose (BMD) modeling include decreased serum antibody concentrations for tetanus and diphtheria (Grandjean et al., 2012; Grandjean et al., 2017b; Budtz-Jørgensen and Grandjean, 2018a) and decreased birth weight (Starling et al., 2017; Shoaff et al., 2018; Manzano-Salgado et al., 2019; Buck Louis et al., 2018; Bach et al., 2016a). The internal doses reported in the human studies were used in the BMD modeling and then converted to human equivalent doses (HEDs) using the pharmacokinetic (PK) model described in Section 3.1 of the main document; the modeling results are presented in this appendix.

#### Modeling Results for Decreased Tetanus Antibody Concentrations at 7 Years of Age and PFHxS Measured at 5 Years of Age

Budtz-Jørgensen and Grandjean (2018a) fit multivariate models of perfluorohexanesulfonic acid (PFHxS) measured at age 5 years, against log_2_-transformed anti-tetanus antibody concentrations measured at the 7-year-old examination controlling for sex, exact age at the 7-year-old examination, and booster type at age 5 years. Models were evaluated with additional control for PFOS (as log_2_[PFOS]) and PFOA (as log_2_[PFOA]), and without PFOS and PFOA. Three model shapes were evaluated by Budtz-Jørgensen and Grandjean (2018a) using likelihood ratio tests: a linear model, a piecewise-linear model with a knot at the median PFHxS concentration, and a logarithmic function. The logarithmic functions did not fit better than the piecewise-linear functions (Budtz-Jørgensen and Grandjean, 2018a). There was evidence that the piecewise-linear model fit better than the linear model for both the PFHxS exposure model without adjustment for PFOS and PFOA (p = 0.002; see Budtz-Jørgensen and Grandjean (2018b) Table 3) and for the model that did adjust for PFOS and PFOA (p = 0.05).

Table D-1 summarizes the results from Budtz-Jørgensen and Grandjean (2018a) for PFHxS at age 5 years and tetanus antibodies at age 7 years. These regression coefficients (β) and their standard errors (SE) were computed by EPA from the published BMDs and BMDL based on a benchmark response (BMR) of 5% decrease in the log_2_-transformed antibody concentration in Table 1 of Budtz-Jørgensen and Grandjean (2018a).^5^ As Budtz-Jørgensen and Grandjean (2018a) log_2_-transformed the outcome variable, the BMR was measured in unit of log_2_[tetanus antibody concentration] as log_2_(1−0.05) = 0.074 log_2_(IU/mL).

Table D-1 Results specific to the low-dose slope from the piecewise- linear analyses of PFHxS measured at age 5 years and log_2_(tetanus antibody concentrations) measured at age 7 from Table 1 in Budtz-Jørgensen and Grandjean (2018a) in a single-PFAS model and in a multi-PFAS model

Exposure | Model shape | PFOS and PFOA adjusted | Slope (β) per ng/mL | SE(β) ng/mL | Slope (β) fit | Lower bound slope (β_LB_)ng/mL
PFHxS at Age 5 | Piecewise | No | −2.47 | 0.75 | p = 0.001 | −3.70
PFHxS at Age 5 | Piecewise | Yes | −1.85 | 1.12 | p = 0.100 | −3.70

Interpretation of results in Table D-1:

- PFHxS is a significant predictor in the single-PFAS model (β = −2.47; p = 0.001).
- Effects of PFHxS in the single-PFAS model are attenuated when log_2_[PFOS] and log_2_[PFOA] are included in the model (β = −1.85; p = 0.100).
- The point estimate results for PFHxS (β) in the single-PFAS model are potentially confounded by PFOS and/or PFOA since there was a 25% reduction in the effect size for PFHxS from −2.47 to −1.85 when controlling for PFOS and PFOA.
  ○ One explanation is that PFOS and/or PFOA was a confounder of the PFHxS effect and controlling for those co-exposures removed confounding.
  ○ Another possibility is that controlling for co-exposures like PFOS and PFOA actually induced confounding (Weisskopf and Webster, 2017; Weisskopf et al., 2018).
  ○ The reasons for the change in main effect size for PFHxS are not known. For this reason, there is uncertainty in knowing which point estimate is the best representation of any effect of PFHxS.
- However, the lower bounds on the point estimates (β_LB_) are the same for the single-PFAS and multi-PFAS models, minimizing the effect of the potential confounding given the lower bound is ultimately used for point-of-departure derivation.
  ○ The definition of the RfD, which is based upon the β_LB_, includes allowing for an order of magnitude (10-fold or 1,000%) uncertainty in the estimate and the uncertainty for potential confounding in the BMD from including, or excluding, PFOS and PFOA here is about 25%, while there is no uncertainty for potential confounding in the BMDL as those values are the same.

#### Selection of the Benchmark Response

The benchmark dose (BMD) approach involves dose-response modeling to obtain BMDs, i.e., dose levels corresponding to specific response levels near the low end of the observable range of the data and the lower limit of the BMD (BMDLs) to serve as potential PODs for deriving quantitative estimates below the range of observation (U.S. EPA, 2012). Selecting a BMR to estimate the BMDs and BMDLs involves making judgments about the statistical and biological characteristics of the data set and about the applications for which the resulting BMDs and BMDLs will be used. An extra risk of 10% is recommended as a standard reporting level for quantal data for toxicological data. Biological considerations may warrant the use of a BMR of 5% or lower for some types of effects as the basis of the POD for a reference value. However, a BMR of 1% has typically been used for quantal human data from epidemiology studies (U.S. EPA, 2012), although this is more typically used for epidemiologic studies of cancer mortality within large cohorts of workers which can support the statistical estimation of small BMRs.

A blood concentration for tetanus antibodies of 0.1 IU/mL is sometimes cited in the tetanus literature as a “protective level” and Grandjean et al. (2017b) noted that the Danish vaccine producer Statens Serum Institut recommended the 0.1 IU/mL “cut-off” level “to determine whether antibody concentrations could be considered protective”; and Galazka and Kardymowicz (1989) mentions the same concentration), but Galazka et al. (1993) argues:

“The amount of circulating antitoxin needed to ensure complete immunity against tetanus is not known for certain. Establishment of a fixed level of tetanus antitoxin does not take into consideration variable conditions of production and adsorption of tetanus toxin in the anaerobic area of a wound or a necrotic umbilical stump. A given serum level could be overwhelmed by a sufficiently large dose of toxin. Therefore, there is no absolute protective level of antitoxin and protection results when there is sufficient toxin-neutralizing antibody in relation to the toxin load (Passen and Andersen, 1986).”

In the absence of a clear definition of what minimal level of change in a continuous endpoint is biologically significant, a default BMR of 1 SD change from the control mean may be selected, as suggested in EPA’s draft Benchmark Dose Technical Guidance Document (U.S. EPA, 2012). As noted above, a lower BMR can also be used if it can be justified on a biological and/or statistical basis. Figure D-1 replicates a figure in the technical guidance (page 23; (U.S. EPA, 2012)) to show that in a control population in which 1.4% are considered to be at risk of having an adverse effect, a downward shift in the control mean of one SD results in a ~10% extra risk of being at risk of having an adverse effect.

Figure D-1 Difference in population tail probabilities resulting from a 1 standard deviation shift in the mean from a standard normal distribution, illustrating the theoretical basis for a baseline BMR of 1 SD

Statistically, the technical guidance additionally suggests that studies of developmental effects can support lower BMRs. Biologically, a BMR of ½ SD is a reasonable choice as anti-tetanus antibody concentrations prevent against tetanus, which is a rare, but severe and sometimes fatal infection, with a case-fatality rate in the United States of 13% during 2001–2008 (Liang et al., 2018). The case-fatality rate can be more than 80% for early lifestages cases (Patel and Mehta, 1999). Selgrade (2007) suggests that specific immunotoxic effects observed in children may be broadly indicative of developmental immunosuppression impacting these children’s ability to protect against a range of immune hazards, which has the potential to be a more adverse effect that just a single immuno-toxic effect. Developmental immunosuppression is even more adverse than decreased anti-tetanus antibody concentrations in children and further justifies the use of a BMR of ½ SD. Thus, decrements in the ability to maintain effective levels of tetanus antitoxins following immunization may be indicative of wider immunosuppression in these children exposed to PFHxS. By contrast, a BMR of 1 SD may be more appropriate for an effect that would be considered “minimally adverse.” A BMR smaller than ½ SD is generally selected for severe effects (e.g., 1% extra risk of cancer mortality); decreased antibody concentrations offer diminished protection from severe effects but are not themselves severe effects.

Following the technical guidance (U.S. EPA, 2012), EPA derived BMDs and BMDLs associated with a 1 SD change in the distribution of log_2_(tetanus antibody concentrations), and ½ SD change in the distribution of log_2_(tetanus antibody concentrations). The SD of the log_2_(tetanus antibody concentrations) at age 7 years was estimated from the distributional data presented in Grandjean et al. (2012) as follows: the interquartile range (IQR) of the tetanus antibody concentrations at age 7 years in IU/mL was (0.65, 4.6). Log_2_-tranforming these values provides the IQR in log_2_(IU/mL) as (−0.62, 2.20). Assuming that these log_2_-transformed values are reasonably represented by a normal distribution, the width of the IQR is approximately 1.35 SDs. Thus, SD = IQR/1.35, and the SD of tetanus antibodies in log_2_(IU/mL) is (2.20 – (−0.62))/1.35 = 2.09 log_2_(IU/mL). To show the impact of the BMR on these results, Table D-2 presents the BMDs and BMDLs at BMRs of ½ SD and 1 SD.

While there was not a clear definition of an adverse effect for a continuous endpoint like antibody concentrations, the value of 0.1 IU/mL is sometimes cited. As a check, EPA evaluated how much extra risk would have been associated with a BMR set at a cut-off value of 0.1 IU/mL. Using the observed distribution of tetanus antibodies at age 7 years in log_2_(IU/mL), EPA calculated that 2.8% of those values would be below the cut-off value of 0.1 IU/mL which is −3.32 log_2_(IU/mL). A BMR of ½ SD resulted in 7.9% of the values being below that cutoff, which is 5.1% extra risk and shows that the generic guidance that a BMR of ½ SD can provide a reasonably good estimate of 5% extra risk. Figure D-2 shows an example.

Figure D-2 Difference in population tail probabilities resulting from a ½ standard deviation shift in the mean from an estimation of the distribution of log_2_(tetanus antibody concentrations at age 7 years)

Table D-2 BMDs and BMDLs for effect of PFHxS at age 5 years on anti-tetanus antibody concentrations at age 7 years using a BMR of ½ SD change in log_2_(tetanus antibodies concentration) and a BMR of 1 SD log_2_(tetanus antibodies concentration)

| Estimated without control of PFOS and PFOA | | Estimated with control of PFOS and PFOA
BMR | BMD (ng/mL); β = −2.47 per ng/mL | BMDL (ng/mL); β_LB_ = −3.70 per ng/mL | BMD (ng/mL); β = −1.85 per ng/mL | BMDL (ng/mL); β_LB_ = −3.70 per ng/mL
½ SD | 0.424 | 0.282^a^ | 0.565 | 0.282
1 SD | 0.847 | 0.565 | 1.130 | 0.565

a Denotes the selected POD.

The lowest serum PFHxS concentration measured at age 5 years was 0.02 ng/mL, the 5th percentile was 0.2 ng/mL, and the 10th percentile was 0.3 ng/mL (Grandjean and Bateson, 2021) so the estimated BMDL for a BMR of ½ SD (BMDL_½ SD_) in the single-PFAS model is at about the 10th percentile of the observed distribution. No information was available to judge the fit of the model in the range of the BMDLs, but the BMD and BMDL were both within the range of observed values and the model fit PFHxS well.

The BMD_½ SD_ estimate from the multi-PFAS models is 33% higher than the BMD_½ SD_ estimate from the models with just PFHxS, but the BMDL_½ SD_ estimates are equal given the lower bounds for both models were equal. The change in BMD estimates may, or may not, reflect control for any potential confounding of the regression effect estimates. While it is not clear which PFAS model provided “better” estimate of the point estimate of the effect of PFHxS, the two BMDL_½ SD_ estimates that serve as the PODs are equal and EPA advanced the derivation based on common BMDL_½ SD_ estimates of 0.282 ng/mL from both the single-PFAS and the multi-PFAS models. However, confidence was somewhat diminished by the potential confounding in the main effect—even though there was no observed confounding of the BMDL. Medium confidence in the BMDLs for PFHxS.

For immunotoxicity related to tetanus associated with PFHxS exposure measured at age 5 years, the POD is based on a BMR of ½ SD and a BMDL½ SD of 0.282 ng/mL.

#### Modeling Results for Decreased Diphtheria Antibody Concentrations at 7 Years of Age and PFHxS Measured at 5 Years of Age

Budtz-Jørgensen and Grandjean (2018a) fit multivariate models of PFHxS measured at age 5 years, against log_2_-transformed anti-diphtheria antibody concentrations measured at the 7-year-old examination controlling for sex, exact age at the 7 year-old examination, and booster type at age 5 years. Models were evaluated with additional control for PFOS (as log_2_[PFOS]) and PFOA (as log_2_[PFOA]), and without PFOS and PFOA. Three model shapes were evaluated by Budtz-Jørgensen and Grandjean (2018a) using likelihood ratio tests: a linear model of PFHxS, a piecewise-linear model with a knot at the median, and a logarithmic function. The logarithmic functions did not fit better than the piecewise-linear functions (Budtz-Jørgensen and Grandjean, 2018a). There was evidence that the piecewise-linear model fit better than the linear model for the PFHxS exposure without adjustment for PFOS and PFOA (p = 0.05; see in Budtz-Jørgensen and Grandjean (2018a), Table 3), but not for the model that adjusted for PFOS and PFOA (p = 0.44). Table D-3 summarizes the results from Budtz-Jørgensen and Grandjean (2018a) for diphtheria in this exposure window. These regression coefficients (β) and their standard errors (SE) were computed by EPA from the published BMDs and BMDL based on a BMR of ½ SD in log_2_(diphtheria antibody concentrations) in Table 1 of Budtz-Jørgensen and Grandjean (2018a).

Table D-3 Results specific to the low-dose slope from the piecewise- linear analyses of PFHxS measured at age 5 years and log_2_(diphtheria antibodies) measured at age 7 years from Table 1 in Budtz-Jørgensen and Grandjean (2018a) in a single-PFAS model and in a multi-PFAS model

Exposure | Model shape | PFOS and PFOA adjusted | Slope (β) per ng/mL | SE(β) ng/mL | Slope (β) fit | Lower bound slope (β_LB_) ng/mL
PFHxS at Age 5 | Piecewise | No | −1.48 | 0.60 | p = 0.0136 | −2.47
PFHxS at Age 5 | Piecewise | Yes | −0.67 | 1.09 | p = 0.537 | −2.47

Interpretation of results in Table D-3:

- PFHxS is a significant predictor in the single-PFAS model (β = −1.48; p = 0.01).
- Effects are attenuated when log_2_[PFOS] and log_2_[PFOA] are included in the model (β = −0.67; p = 0.54).
- The point estimate results for PFHxS are potentially confounded by PFOS and/or PFOA since there was a 55% reduction in the effect size for PFHxS from −1.48 to −0.67 when controlling for PFOS and PFOA.
  ○ One explanation is that PFOS and/or PFOA was a confounder of the PFHxS effect and controlling for those co-exposures removed confounding.
  ○ Another possibility is that controlling for co-exposures like PFOS and PFOA actually induced confounding (Weisskopf and Webster, 2017; Weisskopf et al., 2018).
  ○ The reasons for the change in main effect size for PFHxS are not known. For this reason, there is uncertainty in knowing which point estimate is the best representation of any effect of PFHxS.
- However, the lower bounds on the point estimates (β_LB_) are the same for the single-PFAS and multi-PFAS models, minimizing the effect of the potential confounding given the lower bound is ultimately used for point-of-departure derivation.
  ○ The definition of the RfD, which is based upon the β_LB_, includes allowing for an order of magnitude (10-fold or 1,000%) uncertainty in the estimate and the uncertainty for potential confounding in the BMD from including, or excluding, PFOS and PFOA here is about 55%, while there is no uncertainty for potential confounding in the BMDL as those values are the same.

#### Selection of the Benchmark Response

Following the technical guidance (U.S. EPA, 2012), EPA derived BMDs and BMDLs associated with a one SD change in the distribution of log_2_(diphtheria antibody concentrations), and ½ SD change in the distribution of log_2_(diphtheria antibody concentrations). A blood concentration for diphtheria antibodies of 0.1 IU/mL is sometimes cited in the diphtheria literature as a “protective level” (Grandjean et al., 2017b) noted that the Danish vaccine producer Statens Serum Institut recommended the 0.1 IU/mL “cut-off” level; and Galazka et al. (1993) mentions the same concentration), but Galazka et al. (1993) argues:

“However, it has also been shown that there is no sharply defined level of antitoxin that gives complete protection from diphtheria (Ipsen, 1946). A certain range of variation must be accepted; the same degree of antitoxin may give an unequal degree of protection in different persons. Other factors may influence the vulnerability to diphtheria including the dose and virulence of the diphtheria bacilli and the general immune status of the person infected (Christenson and Böttiger, 1986). Thus, an antibody concentration between 0.01 and 0.09 IU/mL may be regarded as giving basic immunity, whereas a higher titer may be needed for full protection. In some studies that used in vitro techniques, a level of 0.1 IU/mL was considered protective (Galazka and Kardymowicz, 1989; Cellesi et al., 1989).”

Statistically, the technical guidance suggests that studies of developmental effects can support lower BMRs. Biologically, a BMR of ½ SD is a reasonable choice as anti-diphtheria antibody concentrations prevent against diphtheria, which is very rare in the United States, but can cause life-threatening airway obstruction, or cardiac failure (Collier, 1975). Among 13 cases reported in the United States during 1996–2016, no deaths were mentioned (Liang et al., 2018). However, diphtheria remains a potentially fatal disease in other parts of the world Galazka et al. (1993) mentions a case fatality rate of 5%–10%) and PFHxS-related changes in anti-diphtheria antibody concentrations cannot be considered to be ‘minimally adverse’ given the historic lethality of diphtheria in the absence of vaccination. Selgrade (2007) suggests that specific immuno-toxic effects observed in children may be broadly indicative of developmental immunosuppression impacting these children’s ability to protect against a range of immune hazards—which has the potential to be a more adverse effect that just a single immuno-toxic effect.

Following the technical guidance (U.S. EPA, 2012), EPA derived BMDs and BMDLs associated with a one SD change in the distribution of log_2_(diphtheria antibody concentrations) as a standard reporting level, and ½ SD change in the distribution of log_2_(diphtheria antibody concentrations). The SD of the log_2_(diphtheria antibody concentrations) at age 7 years was estimated from the distributional data presented in Grandjean et al. (2012) as follows: the interquartile range (IQR) of the diphtheria antibody concentrations at age 7 years in IU/mL was (0.4, 1.6). Log_2_-tranforming these values provides the IQR in log_2_(IU/mL) as (−1.32, 0.68). Assuming that these log_2_-transformed values are similar to the normal distribution, the width of the IQR is approximately 1.35 SDs, thus SD = IQR/1.35, and the SD of tetanus antibodies in log_2_(IU/mL) is (0.68 – (−1.32))/1.35 = 1.48 log_2_(IU/mL). To show the impact of the BMR on these results, Table D-4 presents the BMDs and BMDLs at BMRs of ½ SD and 1 SD.

Table D-4 BMDs and BMDLs for effect of PFHxS at age 5 years on anti-diphtheria antibody concentrations at age 7 years using a BMR of ½ SD change in log_2_(diphtheria antibodies concentration) and a BMR of 1 SD log_2_(diphtheria antibodies concentration)

| Estimated without control of PFOS and PFOA | | Estimated with control of PFOS and PFOA
BMR | BMD (ng/mL); β = −1.48 per ng/mL | BMDL (ng/mL); β_LB_ = −2.47 per ng/mL | BMD (ng/mL); β = −0.67 per ng/mL | BMDL (ng/mL); β_LB_ = −2.47 per ng/mL
½ SD | 0.500 | 0.300^a^ | 1.100 | 0.300
1 SD | 1.000 | 0.600 | 2.200 | 0.600

a Denotes the selected POD.

The lowest serum PFHxS concentration measured at age 5 years was 0.02 ng/mL, the 5th percentile was 0.2 ng/mL, and the 10th percentile was 0.3 ng/mL (Grandjean and Bateson, 2021) so the estimated BMDL for a BMR of ½ SD (BMDL_½ SD_) in the single-PFAS model is at the 10th percentile of the observed distribution. No information was available to judge the fit of the model in the range of the BMDLs, but the BMD and BMDL were both within the range of observed values and the model fit PFHxS well.

The BMD_½ SD_ estimate from the multi-PFAS models is 2.2-fold higher than the BMD_½ SD_ estimate from the model with just PFHxS, but the BMDL_½ SD_ is the same, which may, or may not, reflect control for any potential confounding of the regression effect estimates. While it is not clear which PFAS model provided the “better” estimate of the point estimate of the effect of PFHxS, the two BMDL_½ SD_ estimates which serve as the PODs are equal and EPA advanced POD based on common BMDL estimates of 0.300 ng/mL from both the single-PFAS and the multi-PFAS models because the uncertainty regarding potential confounding of the BMDL was low. However, confidence was diminished by the stronger potential confounding in the main effect—even though the was no observed confounding of the BMDL, and overall confidence in the BMDLs for diphtheria was judged to be medium/low confidence.

For immunotoxicity related to diphtheria, associated with PFHxS measured at age 5 years, the POD is based on a BMR of ½ SD and a BMDL½ SD of 0.300 ng/mL.

#### Modeling Results for Decreased Tetanus Antibody Concentrations at 5 Years of Age and Perinatal PFHxS

Budtz-Jørgensen and Grandjean (2018a) fit multivariate models of PFHxS measured perinatally in maternal serum, against log_2_-transformed anti-tetanus antibody concentrations measured at the 5-year-old examination controlling for sex, and exact age at the 5-year-old examination, cohort, and interaction terms between cohort and sex, and between cohort and age. Models were evaluated with additional control for PFOS (as log_2_[PFOS]) and PFOA (as log_2_[PFOA]), and without PFOS and PFOA. Three model shapes of PFHxS were evaluated by Budtz-Jørgensen and Grandjean (2018a) using likelihood ratio tests: a linear model, a piecewise-linear model with a knot at the median, and a logarithmic function. The logarithmic functions did not fit better than the piecewise-linear functions (Budtz-Jørgensen and Grandjean, 2018a). Compared to the linear model, the piecewise-linear model did not fit better than the linear model for either the PFHxS exposure without adjustment for PFOS and PFOA using a likelihood ratio test (p = 0.45; see Budtz-Jørgensen and Grandjean (2018a) Table 3), or for the model that did adjust for PFOS and PFOA (log_2_[PFOS] and log_2_[PFOA]) (p = 0.90).

Table D-5 summarizes the results from Budtz-Jørgensen and Grandjean (2018a) for tetanus in this exposure window. These regression coefficients (β) and their standard errors (SE) were computed by EPA from the published BMDs and BMDL based on a BMR of ½ SD change in log_2_(tetanus antibody concentrations) in Table 2 of Budtz-Jørgensen and Grandjean (2018a).

Table D-5 Results of the linear analyses of PFHxS measured perinatally and tetanus antibodies measured at age 5 years from Budtz-Jørgensen and Grandjean (2018a) in a single-PFAS model and in a multi-PFAS model

Exposure | Model shape | PFOS and PFOA adjusted | Slope (β) per ng/mL | SE(β) ng/mL | Slope (β) fit | Lower bound slope (β_LB_) ng/mL
Perinatal PFHxS | Linear | No | −0.0238 | 0.0183 | p = 0.19 | −0.0540
Perinatal PFHxS | Linear | Yes | −0.0190 | 0.0184 | p = 0.30 | −0.0492

Interpretation of results in Table D-5:

- PFHxS is a nonsignificant predictor in the single-PFAS model (β = −0.0238; p = 0.190).
- Effects are attenuated when log_2_[PFOS] and log_2_[PFOA] are included in the model (β = − 0.019; p = 0.30).
- The point estimate results for PFHxS are potentially confounded by PFOS and/or PFOA since there was a 20% reduction in the effect size for PFHxS from −0.0238 to −0.0190 when controlling for PFOS and PFOA.
  ○ One explanation is that PFOS and/or PFOA was a confounder of the PFHxS effect and controlling for those co-exposures removed confounding.
  ○ Another possibility is that controlling for co-exposures like PFOS and PFOA actually induced confounding (Weisskopf and Webster, 2017; Weisskopf et al., 2018).
  ○ The reasons for the change in main effect size for PFHxS are not known. For this reason, there is uncertainty in knowing which point estimate is the best representation of any effect of PFHxS.
- However, the lower bound on the point estimates (β_LB_) for the single-PFAS model is 35% lower than the multi-PFAS model estimate for PFHxS.

The definition of the RfD, which is based upon the β_LB_, includes allowing for an order of magnitude (10-fold or 1,000%) uncertainty in the estimate and the uncertainty for potential confounding in the BMD from including, or excluding, PFOS and PFOA here is about 20%, while the uncertainty for potential confounding in the BMDL is about 9%.

#### Selection of the Benchmark Response

Following the technical guidance (U.S. EPA, 2012), EPA derived BMDs and BMDLs associated with a one SD change in the distribution of log_2_(tetanus antibody concentrations), and ½ SD change in the distribution of log_2_(tetanus antibody concentrations). The SD of the log_2_(tetanus antibody concentrations) at age 5 years was estimated from two sets of distributional data presented from two different cohorts of 5-year-olds that were pooled in Budtz-Jørgensen and Grandjean (2018a). Grandjean et al. (2012) reported on 587 5-year-olds from the cohort of children born during 1997–2000 and in Grandjean et al. (2017b) reported on 349 5-year-olds from the cohort of children born during 2007–2009. The means and SDs were computed separately and then pooled to describe the common SD. The IQR of the tetanus antibody concentrations in the earlier birth cohort at age 5 years in IU/mL was (0.1, 0.51). Log_2_-tranforming these values provides the IQR in log_2_(IU/mL) as (−3.32, −0.97). Assuming that these log_2_-transformed values are similar to the normal distribution, the width of the IQR is approximately 1.35 SDs, thus SD = IQR/1.35, and the SD of tetanus antibodies in log_2_(IU/mL) is (−0.97 – (−3.32))/1.35 = 1.74 log_2_(IU/mL). The IQR of the tetanus antibody concentrations in the later birth cohort at age 5 years in IU/mL was (0.1, 0.3). Log_2_-tranforming these values provides the IQR in log_2_(IU/mL) as (−3.32, −1.74), and the SD of tetanus antibodies in log_2_(IU/mL) is (−1.74 – (−3.32))/1.35 = 1.17 log_2_(IU/mL). The pooled variance is a weighted sum of the independent SDs and the pooled SD was estimated as 1.55 log_2_(IU/mL).^6^ To show the impact of the BMR on these results, Table D-6 presents the BMDs and BMDLs at BMRs of ½ SD and 1 SD.

Table D-6 BMDs and BMDLs for effect of PFHxS measured perinatally and anti-tetanus antibody concentrations at age 5 years

| Estimated without control of PFOS and PFOA | | Estimated with control of PFOS and PFOA
BMR | BMD (ng/mL); β = −0.0238 per ng/mL | BMDL (ng/mL); β_LB_ = −0.0540 per ng/mL | BMD (ng/mL); β = −0.0190 per ng/mL | BMDL (ng/mL); β_LB_ = −0.049 per ng/mL
½ SD | 32.5 | 14.4^a^ | 40.8 | 15.7
1 SD | 65.1 | 28.7 | 81.6 | 31.5

a Denotes the POD that corresponds to the analyses of PFHxS concentrations perinatally and tetanus antibodies at age 5 years.

The lowest perinatal maternal serum PFHxS concentration measured was 0.6 ng/mL, the 5th percentile was 1.2 ng/mL, and the 10th% was 1.5 ng/mL (Grandjean and Bateson, 2021) so the estimated BMDLs for a BMR of ½ SD (BMDL_½ SD_ =14.4 ng/mL) in the single-PFAS model is well above the 10th% of the observed distribution. No information was available to judge the fit of the model in the range of the BMDLs, but the BMD and BMDL were both within the range of observed values and the model fit PFHxS well. The BMDL_½ SD_ estimate from the single-PFAS models was 14.4 ng/mL. The BMDL estimates from the multi-PFAS models were about 9% higher than for the single-PFAS model.

Low confidence in the BMDLs from the PFHxS-only model (14.4 ng/mL) and in the multi-PFAS model (15.7 ng/mL). Confidence is diminished by the low quality of the model fit for PFHxS in either model compared with the PFHxS results from tetanus in the 5-year to 7-year exposure-outcome window of time and there is some uncertainty regarding potential confounding.

For immunotoxicity related to tetanus, associated with PFHxS measured perinatally, the POD is based on a BMR of ½ SD and a BMDL_½ SD_ of 14.4 ng/mL. Note that this result is based on a poorly fit PFHxS regression parameter (β) estimated as −0.024 per ng/mL (90% CI: −0.054, 0.0.0064; p = 0.19) (Budtz-Jørgensen and Grandjean, 2018b), and thus this POD is identified with low confidence.

For immunotoxicity related to tetanus associated with PFHxS exposure measured at age 5 years, the POD estimated for comparison purposes were based on a BMR of ½ SD and a BMDL½ SD of 14.4 ng/mL.

#### Modeling Results for Decreased Diphtheria Antibody Concentrations at 5 Years of Age and Perinatal PFHxS

Budtz-Jørgensen and Grandjean (2018a) fit multivariate models of PFHxS measured perinatally, against log_2_-transformed anti-diphtheria antibody concentrations measured at the 5 year-old examination controlling for sex and age. Models were evaluated with additional control for PFOS (as log_2_[PFOS]) and PFOA (as log_2_[PFOA]), and without PFOS and PFOA. Three model shapes were evaluated by Budtz-Jørgensen and Grandjean (2018a) using likelihood ratio tests: a linear model of PFHxS, a piecewise-linear model with a knot at the median, and a logarithmic function. The logarithmic functions did not fit better than the piecewise-linear functions (Budtz-Jørgensen and Grandjean, 2018a). The piecewise-linear model did not fit better than the linear model for the PFHxS exposure without adjustment for PFOS and PFOA using a likelihood ratio test (p = 0.70; see Budtz-Jørgensen and Grandjean (2018a) Table 3), or for the model that did adjust for PFOS and PFOA (log_2_[PFOS] and log_2_[PFOA]) (p = 0.11). Table D-7 summarizes the results from Budtz-Jørgensen and Grandjean (2018a) for diphtheria in this exposure window. These regression coefficients (β) and their standard errors (SE) were computed by EPA from the published BMDs and BMDL based on a BMR of ½ SD change in log_2_(diphtheria antibody concentrations) in Table 2 of (Budtz-Jørgensen and Grandjean, 2018a).

Table D-7 Results of the analyses of PFHxS measured perinatally and diphtheria antibodies measured at age 5 years from Budtz-Jørgensen Budtz-Jørgensen and Grandjean (2018b) in a single-PFAS model and in a multi-PFAS model

Exposure | Model shape | PFOS and PFOA adjusted | Slope (β) per ng/mL | SE(β) | Slope (β) fit | Lower bound slope (β_LB_)
Perinatal PFHxS | Linear | No | −0.0378 | 0.0193 | p = 0.05 | −0.0696
Perinatal PFHxS | Linear | Yes | −0.0328 | 0.0193 | p = 0.089 | −0.0645

Interpretation of results in Table D-7:

- PFHxS is a significant predictor in the single-PFAS model (β = −0.0378; p = 0.05.)
- Effects of PFHxS are attenuated when PFOA and PFOA are in the model (β = −0.0328; p = 0.09).
- Results for PFHxS are potentially confounded by PFOS and/or PFOA since there was a 13% change in the effect size for PFHxS from −0.038 to −0.033 when controlling for PFOS and PFOA.
  ○ One explanation is that PFOS and/or PFOA was a confounder of the PFHxS effect and controlling for those co-exposures removed confounding.
  ○ Another possibility is that controlling for co-exposures like PFOS and PFOA actually induced confounding (Weisskopf and Webster, 2017; Weisskopf et al., 2018).
- The reasons for the change in main effect size for PFHxS are not known. For this reason, there is uncertainty in knowing which point estimate is the best representation of any effect of PFHxS. However, the lower bounds on the point estimates (β_LB_) are similar with the lower bound on the multi-PFAS model effect estimate for PFHxS only 9% lower than the single-PFAS model effect estimate for PFHxS. This small difference suggests very little uncertainty attributable to potential confounding of the lower bound effect estimates.
  ○ The definition of the RfD, which is based upon the β_LB_, includes allowing for an order of magnitude (10-fold or 1,000%) uncertainty in the estimate and the uncertainty for potential confounding in the BMD from including, or excluding, PFOS and PFOA here is about 13%, while the uncertainty for potential confounding in the BMDL is about 9%.

#### Selection of the Benchmark Response

Following the technical guidance (U.S. EPA, 2012), EPA derived BMDs and BMDLs associated with a one SD change in the distribution of log_2_(tetanus antibody concentrations) as a standard reporting level, and ½ SD change in the distribution of log_2_(tetanus antibody concentrations). The SD of the log_2_(diphtheria antibody concentrations) at age 5 years was estimated from two sets of distributional data presented from two different birth cohorts of 5-year-olds that were pooled in Budtz-Jørgensen and Grandjean (2018a). Grandjean et al. (2012) reported on 587 5-year-olds from the cohort of children born during 1997–2000 and Grandjean et al. (2017b) reported on 349 5-year-olds from the cohort of children born during 2007–2009. The means and SDs were computed separately and then pooled to describe the common SD. The IQR of the diphtheria antibody concentrations in the earlier birth cohort at age 5 years in IU/mL was (0.05, 0.4). Log_2_-tranforming these values provides the IQR in log_2_(IU/mL) as (−4.32, −1.32). Assuming that these log_2_-transformed values are similar to the normal distribution, the width of the IQR is approximately 1.35 SDs, thus SD = IQR/1.35, and the SD of diphtheria antibodies in log_2_(IU/mL) is (−1.32 – (−4.32))/1.35 = 2.22 log_2_(IU/mL). The IQR of the diphtheria antibody concentrations in the later birth cohort at age 5 years in IU/mL was (0.1, 0.3). Log_2_-tranforming these values provides the IQR in log_2_(IU/mL) as (−3.32, −1.74), and the SD of diphtheria antibodies in log_2_(IU/mL) is (−1.74 – (−3.32))/1.35 = 1.17 log_2_(IU/mL). The pooled variance is a weighted sum of the independent SDs and the pooled SD was estimated as 1.90 log_2_(IU/mL).^7^ To show the impact of the BMR on these results, Table D-8 presents the BMDs and BMDLs at BMRs of ½ SD and 1 SD.

Table D-8 BMDs and BMDLs for effect of PFHxS measured perinatally and anti-diphtheria antibody concentrations at age 5 years

| Estimated without control of PFOS and PFOA | | Estimated with control of PFOS and PFOA
BMR | BMD (ng/mL); β = −0.0378 per ng/mL | BMDL (ng/mL); β_LB_ = −0.0696 per ng/mL | BMD (ng/mL); β = −0.0328 per ng/mL | BMDL (ng/mL); β_LB_ = −0.0645 per ng/mL
½ SD | 25.1 | 13.7^a^ | 29.0 | 14.7
1 SD | 50.2 | 27.3 | 57.9 | 29.4

a Denotes the POD that corresponds to the analyses of PFHxS concentrations perinatally and diphtheria antibodies at age 5 years.

The lowest serum PFHxS concentration measured perinatally was 0.6 ng/mL, the 5th percentile was 1.2 ng/mL, and the 10th% was 1.5 ng/mL (Grandjean and Bateson, 2021) so the estimated BMD for a BMR of ½ SD (BMDL_½ SD_) in the single-PFAS model is well within the observed range. No information was available to judge the fit of the model in the range of the BMDLs, but the BMD and BMDL were both within the range of observed values and the model fit PFHxS well.

The BMD_½ SD_ estimate from the multi-PFAS models is 15% higher than the BMD_½ SD_ estimated from the model with just PFHxS, and the BMDL_½ SD_ is 8% higher, which may, or may not, reflect control for any potential confounding of the regression effect estimates. While it is not clear which estimate is “better,” the BMDLs which serve as the PODs are similar (13.7 ng/mL versus 14.7 ng/mL) and EPA advanced the derivation based on results that did not control for PFOS and PFOA because this model appeared to fit PFHxS well (p = 0.05) and there was low uncertainty due to potential confounding in either the BMD or the BMDL. Medium confidence in the BMDLs from PFHxS linear model (13.7 ng/mL) since the model fit reasonably well and these BMDLs do not show meaningful uncertainty about confounding.

For immunotoxicity related to diphtheria, associated with PFHxS measured at age 5 years, the POD is based on a BMR of ½ SD and a BMDL½ SD of 13.7 ng/mL.

#### Modeling Results for Decreased Birth Weight Using Individual Studies

As noted in Section 5.2.1 five high confidence studies (Starling et al., 2017; Shoaff et al., 2018; Manzano-Salgado et al., 2019; Buck Louis et al., 2018; Bach et al., 2016a) reported decreased birth weight in infants whose mothers were exposed to PFHxS. All five studies reported their exposure metric in units of ng/mL. Three studies reported the β coefficients per ln(ng/mL) or per log_2_(ng/mL), one study reported a β coefficients per ln(1+ng/mL) and one study reported a β coefficients per ng/mL, along with 95% confidence intervals (CIs), estimated from linear regression models. The logarithmic transformation of exposure yields a negative value for low numbers, which can result in implausible results from dose-response modeling (i.e., estimated risks are negative and unable to determine the responses at zero exposure). EPA first re-expressed the reported β coefficients in terms of per ng/mL, if necessary, according to Dzierlenga et al. (2020). Then EPA used the re-expressed β and lower limit on the CI to estimate BMD and BMDL values using the general equation y = mx + b, where y is birth weight and x is exposure, substituting the re-expressed β values from these studies for m. The intercept b represents the baseline value of birth weight in an unexposed population and it can be estimated through ȳ = mx̅ + b using an average birth weight from an external population as ȳ, an average exposure as x̅ and re-expressed β from the studies as m.

The CDC Wonder site (https://wonder.cdc.gov/natality.html) provides vital statistics for babies born in the United States. There were 3,791,712 all live births in the United States in 2018 according to final natality data. The mean and standard deviation of birth weight were 3261.6 ± 590.7 g (7.19 ± 1.30 lb), with 8.27% of live births falling below the public health definition of low birth weight (i.e., <2,500 g, or 5.5 lb). The full natality data for the U.S. data on birth weight was used as it is more relevant for deriving toxicity values for the U.S. general population than the study-specific birthweight data. Also, the CDC Wonder database may be queried to find the exact percentage of the population falling below the cut-off value for clinical adversity. America’s Children and the Environment (ACE) Biomonitoring on Perfluorochemicals report (https://www.epa.gov/americaschildrenenvironment/ace-biomonitoring-perfluorochemicals-pfcs#B6 (https://www.epa.gov/americaschildrenenvironment/ace-biomonitoring-perfluorochemicals-pfcs%23B6)) provides the median blood serum levels of PFHxS of 0.6 ng/mL in 2015–2016 in women aged 16 to 49, using National Health and Nutrition Examination Survey (NHANES) as data source. These values are assumed to be representative of women of reproductive age and are subsequently used in the estimation of BMD and BMDL values from the available five epidemiological studies.

Buck Louis et al. (2018) reported a β coefficient of −17.1 g ( 95% CI: −40.7, 6.5) per 1 SD increase of ln(1+ng/mL), corresponding to a rescaled β coefficient of −53.1 g ( 95% CI: −126.4, 20.2) per ln(1+ng/mL) increase, for the association between birth weight and maternal PFHxS serum concentrations (collected during 10 weeks to 13 weeks and 6 days of pregnancy with a median of 12 weeks) in a United States cohort, based on their multiple linear regression (y = m ∗ ln(1 + x) + b) analysis. The reported β coefficient can be re-expressed in terms of per ng/mL according to Dzierlenga et al. (2020). Given the median (0.71 ng/mL) and IQR (0.44–1.23 ng/mL) of the exposure from Buck Louis et al. (2018), EPA estimated the distribution of exposure by assuming the exposure follows a log-normal distribution and the natural logarithm of exposure is normally distributed with mean and standard deviation as:

μ = l n (q_50_) = l n (0.71) = − 0.35 (D-1)

σ = l n (q_75_ / q_25_) / 1.349 = l n (1.23 / 0.44) / 1.349 = 0.75 (D-2)

Then, EPA estimated the 25th – 75th percentiles at 10 percentile intervals of the exposure distribution and corresponding responses of reported β coefficient. The re-expressed β coefficient is determined by minimizing the sum of squared differences between the curves generated by the re-expressed β and the reported β. This resulted in a re-expressed β coefficient of −29.9 g ( 95% CI: −71.1, 11.4) per ng/mL.

Typically, for continuous data, the preferred definition of the benchmark response (BMR) is to have a basis for what constitutes a minimal level of change in the endpoint that is biologically significant. For birth weight, there is no accepted percent change that is considered adverse. However, there is a clinical measure for what constitutes an adverse response: babies born weighing less than 2,500 g are considered to have low birth weight, and further, low birth weight is associated with a wide range of health conditions throughout life (Tian et al., 2019a; Reyes and Mañalich, 2005; Hack et al., 1995). Given this clinical cut-off for adversity and that 8.27% of all live births in the United States in 2018 fell below this cut-off, the hybrid approach can be used to define the BMR. The hybrid approach is advantageous in that it harmonizes the definition of the BMR for continuous data with that for dichotomous data^8^. Essentially, the hybrid approach involves the estimation of the dose that increases the percentile of responses falling below (or above) some cut-off for adversity in the tail of the response distribution. Application of the hybrid approach requires the selection of an extra risk value for BMD estimation. In the case of birth weight, an extra risk of 5% is selected given that this level of response is typically used when modeling developmental responses from toxicology studies, and that low birthweight confers increased risk for adverse health effects throughout life, thus supporting a BMR lower than the standard BMR of 10% extra risk.

Therefore, given a background response and a BMR = 5% extra risk, the BMD would be the dose that results in 12.86% of the responses falling below the 2500 g cut-off value:

E x t r a R i s k (E R) = (P (d) − P (0)) / (1 − P (0)) (D-3)

P (d) = E R (1 − P (0)) + P (0) = 0.05 (1 − 0.0827) + 0.0827 = 0.1286 (D-4)

Using the mean birth weight for all births in the United States of 3,261.6 g with a standard deviation of 590.7 g, EPA calculated the mean response that would be associated with the 12.86th percentile of the distribution falling below 2,500 g. In this case, the mean birth weight would be 3169.2g. Given the median exposure of 0.60 ng/mL from ACE Biomonitoring on Perfluorochemicals as x̅, the mean birth weight in the United States as ȳ and the re-expressed β as m term, the intercept b can be estimated as:

b = y¯ − m x¯ = 3261.6 g − (− 29.9 g ((n g)/(m L))^− 1^) 0.60 (n g)/(m L) = 3279.6 g (D-5)

The BMD was calculated by rearranging the equation y = mx + b and solving for x, using 3279.6 g for the b term and −29.9 for the m term. This resulted in a value of 3.70 ng/mL:

x = (y − b) / m = (3169.2 g − 3279.6 g) / (− 29.9 g ((n g)/(m L))^− 1^) = 3.70 n g / m L (D-6)

To calculate the BMDL, the method is essentially the same except that the lower limit (LL) on the β coefficient (−71.1) is used for the m term. However, Buck Louis et al. (2018) reports a two-sided 95% CI: for the β coefficient, meaning that the lower limit of that CI corresponds to a 97.5% one-sided lower limit. The BMDL is defined as the 95% lower limit of the BMD (i.e., corresponds to a two-sided 90% CI), so the corresponding lower limit on the β coefficient needs to be calculated before calculating the BMDL. First, the standard error of the β coefficient can be calculated as:

S E = (U p p e r L i m i t − L o w e r L i m i t)/(3.92) = (11.4 g ((n g)/(m L))^− 1^ − (− 71.1 g ((n g)/(m L))^− 1^))/(3.92) = 21.0 g ((n g)/(m L))^− 1^ (D-7)

Then the corresponding 95% one-sided lower bound on the β coefficient can be calculated as:

95 % o n e − s i d e d L L = β − 1.645 (S E (β)) = − 29.9 g ((n g)/(m L))^− 1^ − 1.645 (21.0 g ((n g)/(m L))^− 1^) = − 64.4 g ((n g)/(m L))^− 1^ (D-8)

Using this value for the m term results in a BMDL value of 1.71 ng/mL maternal serum concentration.

Shoaff et al. (2018) reported a β coefficient of −13.4 g ( 95% CI: −35.9, 9.1) per ng/mL increase for the association between birth weight and maternal PFHxS serum concentrations (collected during 16 weeks of pregnancy to delivery with a median of 16 weeks) in a United States cohort. A BMD of 7.50 ng/mL was calculated from Shoaff et al. (2018) using the same approach as above with the same values for the mean birth weight in the United States and the reported β coefficient directly without re-expression.

To calculate the BMDL, the same procedure as above is used to calculate the 95% one-sided lower limit for the reported β coefficient from the reported lower limit on the 95% two-sided CI of −35.9 g per ng/mL. Using the corresponding lower limit (−32.3 g per ng/mL), a BMDL of 3.12 ng/mL is calculated.

Starling et al. (2017) reported a β coefficient of −13.5 g ( 95% CI: −50.7, 23.7) per ln(ng/mL) for the association between birth weight and maternal PFHxS serum concentrations (collected during 20 to 34 weeks of pregnancy with a median of 27 weeks) in a United States cohort. Given median (0.8 ng/mL) and IQR (0.5–1.2 ng/mL) of the exposure, EPA estimated the mean (−0.22) and standard deviation (0.65) of the natural logarithm of exposure. The re-expressed β coefficient is −16.2 g ( 95% CI: −60.7, 28.4) per ng/mL and the intercept b is 3271.3 g. The 95% one-sided lower limits for the re-expressed β coefficient is −53.6 g per ng/mL. The values of the BMD and BMDL are 6.32 ng/mL and 1.91 ng/mL, respectively.

(Manzano-Salgado et al., 2019) reported a β coefficient of −8.6 g ( 95% CI: −32.0, 14.8) per log_2_ (ng/mL) for the association between birth weight and maternal PFHxS serum concentrations (collected during the first trimester of pregnancy with a mean of 12.3 weeks) in a Spanish cohort. Given the median (0.58 ng/mL) and SD (0.37 ng/mL) of the exposure, EPA estimated the mean (−0.72) and standard deviation (0.58) of the natural logarithm of exposure. The re-expressed β coefficient is −24.5 g ( 95% CI: −91.2, 42.2) per ng/mL and the intercept is 3276.3 g. The 95% one-sided lower limits for the re-expressed β coefficient is −80.5 g per ng/mL. The values of the BMD and BMDL are 4.37 ng/mL and 1.33 ng/mL, respectively.

Bach et al. (2016b) reported a β coefficient of −11.0 g ( 95% CI: −32.0, 9.0) per IQR increase in PFHxS (ng/mL), corresponding to a rescaled β coefficient of −40.7 g ( 95% CI: −118.5, 33.3) per ng/mL increase, for the association between birth weight and maternal PFHxS serum concentrations (collected 9–20 weeks of pregnancy, 96% within 13 weeks) in a Danish cohort. The BMD of 2.87 ng/mL and BMDL 1.12 ng/mL was calculated using the rescaled β coefficient directly without re-expression.

For all of the above calculations, EPA used the exact percentage (8.27%) of live births in the United States in 2018 that fell below the cut-off of 2,500 g as the tail probability to represent the probability of extreme (“adverse”) response at zero dose (P(0)). However, this exact percentage of 8.27% was calculated without accounting for the existence of background PFHxS exposure in the United States population (i.e., 8.27% is not the tail probability of extreme response at zero dose). Thus, EPA considers an alternative control-group response distribution (N(μ_c_, σ_c_)), using the study-specific intercept b obtained through equation (D-5) (representing the baseline value of birth weight in an unexposed population) as μ_c_ and the standard deviation of U.S. population as σ_c_, to estimate the tail probability that fell below the cut-off of 2500 g. EPA estimated the study-specific tail probability of live births falling below the public health definition of low birth weight (2,500 g) as:

P (0) = (1)/(σ_c_ sqrt(2 π)) ∫_− ∞_^2500^ e^(((x − b)^2^)/(2 σ_c_^2^))^ d x = (1)/(590.7 sqrt(2 π)) ∫_− ∞_^2500^ e^(− ((x − b)^2^)/(2 ∗ 5907^2^))^ d x b = y¯ − m x¯ = 3261.6 − (β_r e − exp r e s s e d_ ∗ 0.60 (n g)/(m L)) (D-9)

In this alternative approach, P(0) is 9.86% if there is no background exposure (x̅ = 0). By using the median of serum PFHxS concentrations (0.60 ng/mL) from ACE Biomonitoring on Perfluorochemicals as background exposure (x̅), the tail probabilities using this alternative approach were study-specific and ranged from 9.35% – 9.65%. As such, the results from this alternative approach, presented under the column of “Alternative Tail Probability” in Table D-9, are very similar to the main results, presented under the column of “Exact Percentage” in Table D-9, when background exposure was not accounted for while estimating the tail probability.

The SAS code and results are provided by (Ru, 2024). Table D-9 presents the BMDs and BMDLs for all individual studies considered for POD derivation, with and without accounting for background exposure while estimating the percentage of the population falling below the cut-off value from (Ru, 2024). The BMDLs across the studies and approaches ranged from 1.12 ng/mL to 4.20 ng/mL.

Table D-9 BMDs and BMDLs for effect of PFHxS on decreased birth weight, by using percentage (8.27%) of live births falling below the public health definition of low birth weight, or alternative study-specific tail probability

Study | Exposure median (IQR or 33-67QR or SD) | Exposure distribution (μ, σ) | Reported β (95% CI) | Re-expressed β (95% CI) g/ng/mL | Intercept b | SE of β | 95% one-sided LL of β | Exact percentage (P(0)=8.27%) | | Alternative tail probability^a^
Study | Exposure median (IQR or 33-67QR or SD) | Exposure distribution (μ, σ) | Reported β (95% CI) | Re-expressed β (95% CI) g/ng/mL | Intercept b | SE of β | 95% one-sided LL of β | BMD (ng/mL) | BMDL (ng/mL) | P(0) | BMD (ng/mL) | BMDL (ng/mL)
(Bach et al., 2016b) | 0.47 (0.36–0.63) | (−0.76, 0.41) | −11.0 (−32.0, 9.0) g/IQR(ng/mL) | −40.7 (−118.5, 33.3) | 3,286.1 | 38.74 | −104.5 | 2.87 | 1.12 ^b^ | 9.16% | 3.44 | 1.34
(Buck Louis et al., 2018) | 0.71 (0.44–1.23) | (−0.35, 0.75) | −17.1 (−40.7, 6.5) g/SD (ln(1+ng/mL)) | −29.9 (−71.1, 11.4) | 3,279.6 | 21.0 | −64.4 | 3.70 | 1.71 | 9.35% | 4.63 | 2.14
(Manzano Salgado et al., 2019) | 0.58 (0.37) | (−0.72, 0.58) | −8.6 (−32.0, 14.8) g/log2(ng/mL) | −24.5 (−91.2, 42.2) | 3,276.3 | 34.0 | −80.5 | 4.37 | 1.33 | 9.44% | 5.60 | 1.71
(Shoaff et al., 2018) | 1.5 (1.0–2.0) | (0.41, 0.79) | −13.4 (−35.9, 9.1) g/ng/mL | −13.4 (−35.9, 9.1) | 3,269.7 | 11.5 | −32.3 | 7.50 | 3.12 | 9.63% | 10.11 | 4.20
(Starling et al., 2017) | 0.8 (0.5–1.2) | (−0.22, 0.65) | −13.5 (−50.7, 23.7) g/ln(ng/mL) | −16.2 (−60.7, 28.4) | 3,271.3 | 22.7 | −53.6 | 6.32 | 1.91 | 9.58% | 8.41 | 2.54

a The alternative study-specific tail probability of live births falling below the public health definition of low birth weight based on normal distribution with intercept b as mean and standard deviation of 590.7 based on U.S. population.

b Smallest BMDL using the five individual studies.

ACE Biomonitoring on Perfluorochemicals also provides the median blood serum levels of PFHxS among women ages 16 to 49 in 1999–2000 (1.3 ng/mL), in 2003–2004 (1.4 ng/mL) and in 2011–2012 (0.8 ng/mL). PA performed a sensitivity analysis by estimating BMD and BMDL using these values as background exposures. The results for Bach et al. (2016b) presented in Table D-10, demonstrate the robustness of EPA’s approaches with alternative assumptions on background exposures.

Table D-10 BMDs and BMDLs for effect of PFHxS on decreased birth weight by background exposure, using the exact percentage of the population (8.27%) of live births falling below the public health definition of low birth weight, or alternative study-specific tail

Study | Background exposure ^a^ | Intercept b | Exact percentage (P(0)= 8.27%) | | Alternative tail probability ^b^
Study | Background exposure ^a^ | Intercept b | BMD (ng/mL) | BMDL (ng/mL) | P(0) | BMD (ng/mL) | BMDL (ng/mL)
(Bach et al., 2016b) | 0.60 | 3286.1 | 2.87 | 1.12 | 9.16% | 3.44 | 1.34
(Bach et al., 2016b) | 0.80 | 3294.2 | 3.07 | 1.20 | 8.94% | 3.50 | 1.36
(Bach et al., 2016b) | 1.30 | 3314.6 | 3.57 | 1.39 | 8.39% | 3.65 | 1.42
(Bach et al., 2016b) | 1.40 | 3318.7 | 3.67 | 1.43 | 8.29% | 3.68 | 1.43

a Assumptions on background exposure for the estimation of intercept using Equation (D-3).

b The tail probability of live births falling below the public health definition of low birth weight based on normal distribution.

Uncertainty may be introduced by the re-expression of regression coefficients Linakis et al. (2021). A sensitivity analysis was performed to compare BMD and BMDL with and without re-expression of β coefficients using Buck Louis et al. (2018). Buck Louis et al. (2018) reported a β coefficient of −17.1 g ( 95% CI: −40.7, 6.5) per 1 SD increase of ln(1+ng/mL), corresponding to a rescaled β coefficient of −53.1 g ( 95% CI: −126.4, 20.2) per ln(1+ng/mL) increase. The BMD of 8.12 ng/mL and BMDL 1.79 ng/mL was calculated using the general equation y = m ∗ ln(1 + x) + b and the rescaled β coefficient per ln(1+ng/mL), while assuming the median blood serum levels of PFHxS of 0.60 ng/mL. This approach removed any uncertainty associated with the re-expression of regression coefficients in the modeling. Table D-11 shows the BMD/BMDL results at several background exposure levels using re-expressed β coefficient (g/ng/mL) or reported/rescaled β coefficient (g/ln(1+ng/mL)) for Buck Louis et al. (2018).

Table D-11 BMDs and BMDLs for effect of PFHxS on decreased birth weight by background exposure, using the exact percentage of the population (8.27%) of live births falling below the public health definition of low birth weight, with re-expressed β coefficient (g per ln(1+ng/mL))

Study | Background exposure ^a^ | Intercept b | Re-expressed β g/ng/mL | | Reported/rescaled β g/ln (1+ ng/mL)
Study | Background exposure ^a^ | Intercept b | BMD (ng/mL) | BMDL (ng/mL) | BMD (ng/mL) | BMDL (ng/mL)
(Buck Louis et al., 2018) | 0.60 | 3,279.6 | 3.70 | 1.71 | 8.12 | 1.79
(Buck Louis et al., 2018) | 0.80 | 3,285.5 | 3.90 | 1.80 | 9.26 | 1.94
(Buck Louis et al., 2018) | 1.30 | 3,300.5 | 4.40 | 2.04 | 12.11 | 2.30
(Buck Louis et al., 2018) | 1.40 | 3,303.4 | 4.50 | 2.08 | 12.68 | 2.36

a Assumptions on background exposure for the estimation of intercept using Equation (D-5).

#### Modeling Results for Decreased Birth Weight Using Meta-analysis Results

In addition to the above five studies, epidemiologic data were also available on another 22 studies with different reported units of β coefficient for the association between birth weight and PFHxS concentrations as discussed in the Meta-Analysis Method section (see Appendix C). As noted above, EPA was able to convert the exposure-response functions quantifying the effects for these studies based on different units into natural log units (i.e., per ln(ng/mL)) according to Dzierlenga et al. (2020). Two studies, Lind et al. (2017) and Ashley-Martin et al. (2017) only reported separate estimates for boys and girls; before performing the overall meta-analysis, these estimates were pooled using inverse-variance weighting. The study by Maisonet et al. (2012) and Marks et al. (2019a) only reported sex-specific estimates for girls and boys from the same population. These two studies were also pooled to obtain an effect estimate in the overall population and included in the meta-analysis as Maisonet et al. (2012). Meta-analyses were performed using β coefficient per ln(ng/mL) of all 27 studies, since the majority of the studies reported results on log scale. Additionally, analyses were performed using subsets of the studies to evaluate whether the summary effect estimate varied by study confidence or by the timing of maternal serum sampling. The results were presented in Table D-12.

The meta-analysis conducted using β coefficient per ln(ng/mL) for all studies (n = 27) resulted in a β coefficient of −7.9 g ( 95% CI: −15.0, −0.7) mean birth weight per ln(ng/mL) PFHxS increase based on a random effect model with inverse-variance weights. This β coefficient can be re-expressed in terms of per ng/mL according to Dzierlenga et al. (2020). First, the distribution of exposure for each individual study was estimated by assuming the exposure follows a log-normal distribution. One hundred replicates of random samples (sample size was the same as the reported sample size in each study) were then simulated from the exposure distributions for each study included in the meta-analysis, and random samples from all studies were pooled for each replicate to get quantiles from the pooled random samples for each replicate. Lastly, the mean quantiles (median and IQR) from the 100 replicates were used to obtain the exposure distribution for all studies using Equation (D-1) and (D-2), since the joint distribution of the exposures are also log normally distributed. The re-expressed β coefficient is −8.1 g ( 95% CI: −15.4, −0.7) per ng/mL.

The BMD of 12.02 ng/mL from all studies can be calculated using the same approach as above with the same values for the mean birth weight in the United States. To calculate the BMDL, the same procedure as above was used to calculate the 95% one-sided lower limit for the re-expressed β coefficient. Using the one-sided lower limit, a BMDL of 6.83 ng/mL is calculated.

The BMD and BMDL for the effect of PFHxS on decreased birth weight using meta-analysis results, conducted in log scale overall, and stratified by study confidence and by sample timing, are presented in Table D-12 below. As shown in Table D-12 (and Appendix C), the overall combined β coefficient of −7.9 g ( 95% CI: −15.0, −0.7) per ln(ng/mL) increase was robust and very comparable to that seen for only the twelve high studies (−6.8 g; 95% CI: −16.3, 2.8) or the 23 medium and high studies combined (−8.1 g; 95% CI: −15.4, −0.9). Similarly, the BMDLs for the earlier sampled study subsets (6.24) were very comparable to the overall full set of studies (6.83).

EPA also conducted the analysis with the alternative approach discussed above by considering an alternative control-group response distribution (N(μ_c_, σ_c_)). The results from this alternative approach, presented in Table D-13 below, are very similar to the previous results.

Table D-12 BMDs and BMDLs for effect of PFHxS on decreased birth weight using meta-analysis results conducted in log scale overall, by study confidence and by sample timing, using the percentage (8.27%) of live births falling below the public health definition of low birth weight

Set of studies | Meta-analysis in log scale
Set of studies | β per ln(ng/mL) (95% CI) | Re-expressed β per ng/mL (95% CI) | BMD (ng/mL) | BMDL (ng/mL)
All studies (n = 27) | −7.9 (−15.0, −0.7) | −8.1 (−15.4, −0.7) | 12.02 | 6.83
Study Confidence
High (n = 12) | −6.8 (−16.3, 2.8) | −7.3 (−17.5, 3.0) | 13.25 | 6.08
Medium (n = 11) | −10.0 (−21.1, 1.1) | −9.2 (−19.4, 1.0) | 10.65 | 5.51
Low (n = 4) | −1.5 (−51.6, 48.7) | −3.7 (−127.1, 120.0) | 25.61 | 0.88
High + Medium (n = 23) | −8.1 (−15.4, −0.9) | −8.1 (−15.5, −0.9) | 11.95 | 6.83
Sample Timing^a^
Early Pregnancy (n = 12) | −7.6 (−16.2, 1.1) | −8.0 (−17.0, 1.2) | 12.20 | 6.24
Late Pregnancy (n = 10) | −3.9 (−17.7, 9.9) | −4.7 (−21.2, 11.8) | 20.41 | 5.14
Post Pregnancy (n = 5) | −28.3 (−69.3, 12.7) | −11.7 (−28.7, 5.3) | 8.49 | 3.83
Late + Post Pregnancy (n = 15) | −8.5 (−21.0, 4.1) | −8.2 (−20.3, 4.0) | 11.87 | 5.30

a Sample time periods include early pregnancy (the 1st trimester, 1st, or 2nd trimester), late pregnancy (2nd trimester, 2nd, or 3rd trimester), post pregnancy (birth and post-birth); n = number of studies; effect estimates, β, represent change in birthweight (grams) per unit change in ln (ng/mL) or ng/mL PFHxS exposure; CI = confidence interval.

Table D-13 BMDs and BMDLs for effect of PFHxS on decreased birth weight using meta-analysis results conducted in log scale overall, by study confidence and by sample timing, using the alternative study-specific tail probability of live births falling below the public health definition of low birth weight

Set of studies | Meta-analysis in log scale
Set of studies | β per ln(ng/mL) (95% CI) | Re-expressed β per ng/mL (95% CI) | BMD (ng/mL) | BMDL (ng/mL)
All studies (n = 27) | −7.9 (−15.0, −0.7) | −8.1 (−15.4, −0.7) | 16.83 | 9.45
Study Confidence
High (n = 12) | −6.8 (−16.3, 2.8) | −7.3 (−17.5, 3.0) | 18.41 | 8.45
Medium (n = 11) | −10.0 (−21.1, 1.1) | −9.2 (−19.4, 1.0) | 14.65 | 7.59
Low (n = 4) | −1.5 (−51.6, 48.7) | −3.7 (−127.1, 120.0) | 36.21 | 1.25
High + Medium (n = 23) | −8.1 (−15.4, −0.9) | −8.1 (−15.5, −0.9) | 16.53 | 9.44
Sample Timing^a^
Early Pregnancy (n = 12) | −7.6 (−16.2, 1.1) | −8.0 (−17.0, 1.2) | 16.89 | 8.64
Late Pregnancy (n = 10) | −3.9 (−17.7, 9.9) | −4.7 (−21.2, 11.8) | 28.72 | 7.23
Post Pregnancy (n = 5) | −28.3 (−69.3, 12.7) | −11.7 (−28.7, 5.3) | 11.54 | 5.21
Late + Post Pregnancy (n = 15) | −8.5 (−21.0, 4.1) | −8.2 (−20.3, 4.0) | 16.41 | 7.33

a Sample time periods include early pregnancy (the 1st trimester, 1st or 2nd trimester), late pregnancy (2nd trimester, 2nd or 3rd trimester), post pregnancy (birth and post-birth); n = number of studies; effect estimates, β, represent change in birthweight (grams) per unit change in ln (ng/mL) or ng/mL PFHxS exposure; CI = confidence interval.

#### Summary of Modeling Results for Decreased Birth Weight

For decreased birth weight associated with PFHxS exposure, the POD selected from the available epidemiologic literature (considering both individual studies and the results of meta-analyses using either high and medium confidence studies or focusing on early trimester sample timing) is 1.12 ng/mL maternal serum concentration, based on birth weight data from Bach et al. (2016a). The PODs from the meta-analyses of high, medium, or early sampling time studies were higher than the PODs from individual study PODs, and thus were not considered health-protective and were not considered further for POD selection. Of the five individual studies, (Manzano-Salgado et al., 2017; Buck Louis et al., 2018; Bach et al., 2016a) assessed maternal PFHxS serum concentrations either exclusively or predominately in the first trimester, minimizing concerns surrounding bias due to pregnancy-related hemodynamic effects. Additionally, use of the Bach et al. (2016a) results expressed in natural scale eliminated uncertainty associated with the re-expression of regression coefficients. Therefore, the POD from Bach et al. (2016a), which also was the lowest, was ultimately selected.

### D.1.2 Modeling Results for Increased Serum ALT

PFHxS is associated with increases in the liver enzyme alanine aminotransferase (ALT) (see Section 3.2.4). One medium confidence epidemiology study, Kim et al. (2023b), was selected for the POD derivation. EPA derived multiple estimates of the POD from this study, for men and women, using different benchmark responses (BMRs) and different approaches to define adverse changes. EPA used three different approaches from the EPA Benchmark Technical Guidance (U.S. EPA, 2012) to estimate PODs: the hybrid approach, which uses a biologically based cutoff in the distribution of ALT concentrations to define a level above which ALT may be interpreted as abnormal—or uses a percentile-based approach to define such a level—and a BMR of 10% (or 5%) extra risk beyond that cutoff to estimate a magnitude of exceedance above this cutoff that is (minimally) adverse; the standard deviation approach, which defines the BMR as a change in the mean of one standard deviation (SD) (or ½ SD); and the NOAEL approach.

Kim et al. (2023b) reported percentage change in ln-ALT per log_2_-unit increase in PFHxS defined as a function of the reported regression coefficient (i.e., (e^β^−1)*100). EPA calculated the regression coefficients, and the 95% confidence intervals from the reported percent changes and re-scaled those as slopes of change in ln-ALT(U/L) per ln (ng/mL) PFHxS. Essentially, this study has already performed a dose-response analysis (i.e., the regression analysis), and was interpreted to have adequately accounted for relevant confounding factors in that analysis. EPA did not have access to the individual-level data that would be necessary to model the data from these studies with standard BMDS-based approaches. Therefore, EPA relied on the regression coefficients β from the linear regression models of ln-transformed ALT and ln-transformed PFHxS concentrations in Kim et al. (2023b) as described below to calculate BMD and BMDL values by using the general equation y = βx + b, where y is ln-ALT and x is ln-PFHxS. The unknown intercept b can be estimated using ȳ = βx̅ + b using an average ln-ALT from an external population as ȳ and average ln-PFHxS as x̅.

The National Health and Nutrition Examination Survey (NHANES, https://wwwn.cdc.gov/Nchs/Nhanes/) provides ALT and PFHxS concentrations for the periods of 1999–2018,^9^ for adults age 18 years and over, which can be used to obtain an average ln-ALT as ȳ and ln-PFHxS as x̅ to estimate the intercept b though the equation:

b = y¯ − β x¯ (D-10)

EPA obtained the summary statistics (e.g., mean and SD of ln-ALT and mean of ln-PFHxS) for the period of 1999–2018, separately for men and women ages 18 and over, while using the NHANES survey weights. These analyses used the NHANES-recommended regression model adjustment to correct the 2017–2018 ALT data to match the earlier laboratory method. The mean and SD of ln-ALT and mean of ln-PFHxS for the period of 1999–2018 are reported in Table D-14 by gender.

#### Hybrid Approach

With a regression coefficient β and an estimated intercept b, a BMD can be estimated through the hybrid approach by defining the BMD as the dose yielding the specified extra risk (i.e., the dose that increases the percentage of responses falling below (or above) a cutoff level in the tail of the response distribution (EPA’s Benchmark Dose Technical Guidance (U.S. EPA, 2012)). The hybrid approach is advantageous in that it harmonizes the definition of the BMR for continuous data with that for dichotomous data.

Elevated serum ALT is a biomarker of liver injury and has been associated with a variety of liver diseases. It is commonly used to help diagnose and monitor liver disease, and elevations are common in primary care medicine. ALT is highly abundant in liver, and injury to the organ leads to increased ALT levels, although it should be acknowledged that severe muscle injury may also increase ALT levels in the blood (i.e., it is sensitive but not specific to liver injury) (Thulin et al., 2014). There is a range of “baseline” serum ALT levels across individuals, e.g., Gowda et al. (2009) reference a range of 7–56 U/L across individuals, and elevations of a small magnitude are typically considered nonspecific in relation to liver disease or disease progression. Since ALT concentrations are related to individuals’ age, sex, alcohol consumption, and BMI, different populations will have different sets of baseline risk factors for higher ALT as well as having different anthropometric characteristics like metabolism and genetics (Pacifico et al., 2013).

Valenti et al. (2021) analyzed ALT levels in 21,296 apparently healthy adults (the “whole cohort”) and on a subset of 9,195 who were screened for viral hepatitis, with normal body mass index, cholesterol, triglycerides, and glucose, and without regular alcohol intake or drug use (the “healthy cohort”). Based on the healthy cohort, Valenti et al. (2021) recommended updated ALT upper reference limits, also called the upper limit of normal (ULN), for the International Federation of Clinical Chemistry and Laboratory Medicine (IFCC) of 42 and 30 U/L for males and females, respectively. To test the ability of these cutoffs to predict liver pathology, analysis of a subset of the cohort with dysmetabolism indicated that people with ALT concentrations above the ULNs were at increased risk of steatosis. Park et al. (2019) followed the health of 338,216 people from their baseline visits in 2003–2004 until 2013 (mean follow-up of 9.83 years) and identified 1,048 decompensated liver events (cirrhosis) during that time period. Park et al. (2019) found that people with higher baseline ALT concentrations were at significantly increased risk for decompensated liver events with hazard ratios of 4.43 for men with ALT > 40 U/L (95% CI: 3.80, 5.17) and 4.29 for women with ALT > 40 U/L (95% CI: 3.17, 5.78).

One option for defining a biologically based cutoff in the ALT distribution is to use a definition of the ULN that is typically set at the 95th percentile of ALT in a population of healthy adults and is calculated by individual clinical laboratories or testing sites. The challenge is to define the ULN to detect small but biologically meaningful (adverse) changes. However, EPA is aware that there may be uncertainties in the data underlying published ULNs due to the variability of multiple aspects of measuring ALT in healthy populations. Historically, the measurement of ALT has included many sources of variability in interlaboratory practices Valenti et al. (2021), as well as in the demographic and anthropometric characteristics of the studied population (Pacifico et al., 2013). Although the IFCC has published reference methods and materials for determining ALT in serum (Schumann et al., 2002), persistent challenges remain due to variations in assay conditions and differences in analyzer instruments across laboratory and clinical settings (Infusino I, 2009; Beste et al., 2020). For example, in 2002, Schumann et al. (2002) recommended that the reference temperature for measuring enzyme catalytic concentrations be changed from 30 to 37°C and Schumann and Klauke (2003) proposed new preliminary ALT cutoffs of 45 U/L for men and 34 U/L for women. Thus, many ULNs exist, and they vary considerably depending on features such as when the ULN was developed and the clinical features of patient cohorts upon which it is based.

Similarly, defining the quantitative limit of ULN for ALT is affected by many sources of variability including the definition of the “healthy” reference population, which may not always have excluded blood donors with hepatitis C or could not differentiate people with non-alcoholic fatty liver disease (NAFLD) (Pacifico et al., 2013). Unintentional inclusion of unhealthy people in the reference population can skew ULN results toward higher values. For these reasons, there is no standardized ULN for ALT, including in the United States, and ULNs across laboratories range from <20 U/L to >50 U/L.

Owing to the large size of the study population and the careful attention to standardization of the methods Valenti et al. (2021), EPA used the recently updated IFCC ULNs to define the cutoff in the ALT distribution used in the hybrid approach. Valenti et al. (2021) reported ULNs for men and women as the upper 95th percentile of ALT in a population of apparently healthy blood donors, with robust exclusion criteria that included (among other factors) endemic infectious diseases and alcohol intake. The ULNs established for the healthy group in this study provide a strong foundation for comparison (and are routinely those used in practice) to set ULNs for clinical screening to avoid including conditions that may be causing elevated ALT concentration. However, for the purposes of applying cutoffs in the distribution of ALT to the U.S. population, the cutoffs reported for the larger whole cohort were also considered by EPA as they have the potential to be more generalizable to the U.S. general population, which includes susceptible populations with risk factors for liver disease.

While the ULNs reported by Valenti et al. (2021) were developed for use in identifying patients for additional diagnostic screening, thus introducing some uncertainty regarding their precision in representing a definitive cutoff for increased disease on their own, they can serve to represent a reasonable boundary for detecting liver injury for the purposes of contextualizing a POD. Notably, there is clear evidence that liver injury (and particularly liver disease) is associated with increased ALT concentration in the blood. A further justification for the use of the 95th percentiles of ALT in Valenti et al. (2021), beyond a strictly biological demarcation, is that the Valenti approach to derive the ULN is aligned with the BMD Technical Guidance that suggests the use of a percentile-based approach (U.S. EPA, 2012; Kavlock et al., 1995); given this background, use of the 95th percentile of ALT to define the ULN appears to be reasonable.

The ULN of ALT for liver disease was chosen to be C = 42 U/L for men and C = 30 U/L for women, based on the sex-specific ULNs found for the healthy population (i.e., people without risk factors for liver disease) in Table 2 of Valenti et al. (2021). EPA also considered the alternative cutoffs based on the whole cohort of Valenti et al. (2021) (i.e., C = 48 U/L for men and C = 33 U/L for women).

Given these clinical limits, the percentages above these cutoffs C U/L were obtained as P(0), separately for men and women ages 18 and over for the period of 1999–2018 in the NHANES, while assuming that ALT is lognormally distributed using the equation:

P (0) = 1 − Φ {(l n (C) − m e a n (l n A L T))/(S D (l n A L T))} (D-11)

where Φ is the normal cumulative distribution function.^10^

In addition, application of the hybrid approach requires the selection of an extra risk value for BMD estimation. In the case of ALT, EPA considered both extra risks of 5% and 10% in the BMD estimation. A BMR of less than 10% (or less than 1 SD, see below) can be supported for severe or debilitating health outcomes; given the findings of associations between elevated ALT and severe liver disease in Park et al. (2019), a BMR of 5% was considered. However, modest elevations in ALT are more likely to be associated with mild forms of injury, including steatosis and NAFLD. Due to the uncertainties in measuring ALT, in selecting the most appropriate ULN (and the difficulty in interpreting specific elevations above the ULN as adverse), and in selecting the reference population described above, a BMR of 10% extra risk was selected as a (minimally) adverse effect and as a standard reporting level per the Benchmark Dose Technical Guidance (U.S. EPA, 2012).

The extra risk of adverse effects associated with increased ALT is given by the equation:

E x t r a R i s k = (P (d) − P (0))/(1 − P (0)) (D-12)

where P(d) is the probability of ALT greater than or equal to C (U/L) for a given PFHxS dose d. Thus, P(d) can be solved using the above equation as

P (d) = {1 − P (0)} × E x t r a R i s k + P (0) (D-13)

For a given group and dose, the probability of ALT greater than or equal to C can also be written as

P (d) = P (A L T ≥ C) = P (l n A L T ≥ l n C) = 1 − Φ ((l n C − y)/(S)) (D-14)

where Φ is the normal cumulative distribution function. Thus, with the P(d) derived from equation D-12, the target mean ln ALT that would be associated with the P(d)th percentile of the target distribution falling above C (U/L), denoted as y, is the solution of the last equation, i.e., y = ln C − S × Φ^−1^{1 − P(d)}, where Φ^−1^ is the inverse of the normal cumulative distribution function and S is the standard deviation of y and assumed to be the same as SD of ln-ALT in NHANES.

The ln-PFHxS benchmark dose (ln BMD) is the corresponding dose x such that y = βx + b. Thus

l n B M D = (y − b)/(β) (D-15)

This gives the PFHxS benchmark dose (BMD) as exp(ln BMD).

To calculate the BMDL, the method is essentially the same except that the upper limit (UL) on the β coefficient is used. However, Kim et al. (2023b) reported two-sided 95% confidence intervals for the β coefficients, meaning that the upper limits of those confidence intervals correspond to 97.5% one-sided upper limits. The BMDL is defined as the 95% lower limit of the BMD (i.e., corresponds to a two-sided 90% confidence interval), so the corresponding upper limit on the β coefficient needs to be calculated before calculating the BMDL. First, the standard error of the β coefficient can be calculated as:

s e (β) = (U p p e r L i m i t − L o w e r L i m i t)/(3.92) (D-16)

Then the corresponding 95% one-sided upper bound on the β coefficient can be calculated as:

β 95 = 95 t h o n e − s i d e d U p p e r l i m i t f o r β = β + 1.645 × s e (β) (D-17)

Thus

l n B M D L = (y − b)/(β 95) (D-18)

This gives the PFHxS benchmark dose lower bound (BMDL) as exp(ln BMDL).

Kim et al. (2023b)^11^ examined a sub-population of the Korean National Environmental Health Survey (KoNEHS)^12^ and reported significant percentage changes in ln-ALT for log_2_-unit increase in PFHxS of 2.8% (95% CI: −1.2, 7.0) for men and 3.7% (95% CI: −0.2, 7.8) for women using multiple linear regression adjusted for age, sex, education, income, smoking, heavy drinking, exercise, and body mass index (BMI). The regression coefficients β were calculated as 0.0276 (95% CI: −0.0121, 0.0677) ln ALT(U/L) per log_2_ (ng/mL) PFHxS for men and 0.0363 (95% CI: −0.0020, 0.0751) ln ALT(U/L) per log_2_ (ng/mL) PFHxS for women.^13^ These regression coefficients β can be rescaled to 0.0398 (95% CI: −0.0174, 0.0976) ln ALT(U/L) per ln (ng/mL) PFHxS for men and 0.0524 (95% CI: −0.0029, 0.1084) ln ALT(U/L) per ln (ng/mL) PFHxS for women by dividing each value by ln(2). Using the mean (2.96 ln(U/L) for women) and SD of ln-ALT (0.41 for women) as ȳ and SD(ȳ), the mean of ln-PFHxS (0.12 ln(ng/mL) for women) as x̅, and the percentages falling above the cutoff P(0) (14.0% for women) for the period of 1999–2018 in NHANES, P(d) (22.6% for women) was calculated using equation D-12 with an extra risk of 10%, the intercept b (2.95) was estimated using equation D-9, and the target mean y (3.09 for women) was derived using equation D-13. Similarly, the target mean y was 3.42 for men. EPA estimated that the values of the BMDs for 10% extra risk with the cutoffs of the whole cohort of Valenti et al. (2021) were 64.47 ng/mL for men and 14.91 ng/mL for women using equation D-14. The values of the BMDLs using the same extra risk and cutoffs were 6.58 ng/mL for men and 4.18 ng/mL for women, estimated using equation D-9. The 8.6% upward shift (above the 14% of women above the cutoff at baseline) in the distribution of ln(ALT) using the hybrid method resulting from an extra risk of 10% is illustrated using Figure D-3 below for women using the period of 1999–2018 in NHANES. Note that the 8.6% shift results in 10% extra risk as (P(d)−P(0))/(1−P(0)) = (0.226–0.14)/(1–0.14) = 0.10.

Figure D-3 The shift in the distribution using hybrid method resulting from an extra risk of 10% for Women of Kim et al. (2023b) using the ULN cutoff for the healthy population of Valenti et al. (2021)

Given potential concerns regarding the generalizability of ULN cutoffs based on a different demographic (an Italian cohort) to those populations in which ALT was measured in the selected studies of PFHxS, EPA compared the distribution of ALT in the adult study populations of Kim et al. (2023b) with the distribution of ALT in in the adult population in Valenti et al. (2021). Table D-14 shows the distribution of ALT in Kim et al. (2023b), and Valenti et al. (2021) to be close to each other with Kim et al. (2023b) slightly higher than Valenti et al. (2021).

Table D-14 Distribution of ALT by study and gender

Study | ALT (IU/L) | | ln-ALT (µ, σ)^a^
Kim 2023 All | 21.81 (1.62) | GM(GSD) | (3.08, 0.48)
Kim 2023 Men | 25.93 (1.61) | GM(GSD) | (3.26, 0.48)
Kim 2023 Women | 18.86 (1.54) | GM(GSD) | (2.94, 0.43)
Valenti 2021 Whole Cohort Men | 26.2 (13.3) | Mean(SD) | (3.15, 0.48)
Valenti 2021 Whole Cohort Women | 18.9 (13.5) | Mean(SD) | (2.73, 0.64)
Valenti 2021 Healthy Population Men | 23.7 (12.8) | Mean(SD) | (3.04, 0.51)
Valenti 2021 Healthy Population Women | 18 (8.4) | Mean(SD) | (2.79, 0.44)

a When the mean and standard deviation were presented, EPA estimated μ and σ using μ = I n ( M e a n / sqrt(ω) ) and σ = sqrt(I n ( ω) ) , where ω = 1+ (SD/Mean)^2^ (Limpert et al., 2001).

EPA also derived BMDs and BMDLs using the non-preferred alternative cutoffs based on the whole cohort of Valenti et al. (2021). The parameter choices (e.g., ULN cutoff (C), the reported percent change, the regression coefficient β converted from the reported percent change, the mean and SD of ln-ALT (ȳ), the mean of ln-PFHxS (x̅), P(0), P(d), the intercept b, and the target mean y) and results of BMD and BMDL are presented by extra risk (e.g., 5% or 10%), study, and gender in Table D-15, representing the cutoff for the healthy population in Valenti et al. (2021) and Table D-16 for the cutoff for the whole cohort in Valenti et al. (2021). Unrounded values of summary statistics from NHANES were used in the derivation of BMD and BMDL reported in Tables D-15 and D-16.

The SAS code and results are provided by (Ru, 2024). Table D-15 shows the BMDLs based on the hybrid approach for both Kim et al. (2023b) for BMRs of 10% and 5% using the healthier subset in Valenti et al. (2021). The BMDLs were lower for women than for men, and lower for a BMR of 5% than for 10%. The range across the four combinations was 2.22 ng/mL (Kim et al. (2023b), women, 5%) to 6.58 ng/mL (Kim et al. (2023b), men, 10%). Table D-16 shows the BMDLs based on the hybrid approach for Kim et al. (2023b) for BMRs of 10% and 5% using the whole cohort. The BMDLs were also lower for women than for men, and lower for a BMR of 5% than for 10%. The range across the four combinations was 2.79 ng/mL (Kim et al. (2023b), women, 5%) to 11.29 ng/mL (Kim et al. (2023b), men, 10%).

#### Standard Deviation Approach

In circumstances in which there is no standardized, generally accepted, or well-supported adverse effect level upon which to base the BMR, a standard deviation approach can be useful. For ALT, EPA also estimated a BMD through the standard deviation approach by defining the BMD as the dose yielding the increases of log responses in specified multiples of the standard deviation (SD) of a control group. In contrast to the hybrid approach, which utilizes a cutoff to define a target mean that corresponds to a BMD using equations D-10 through D-13, the target mean ln ALT in the standard deviation approach that would be associated with the increases of log responses, denoted as y, is y = y(0) + S(0) × BMR, where y(0) is the mean of ln-ALT in a control group and S(0) is the standard deviation of y(0). EPA assumed the mean and SD of ln-ALT for the period of 1999–2018 in NHANES as y(0) and S(0) and derived BMDs and BMDLs using equations D-14 through D-17, similar to the hybrid approach in which the intercept b was estimated though the equation D-9.

The parameter choices (e.g., the reported percent change, the regression coefficient β converted from the reported percent change, the mean and SD of ln-ALT (ȳ), the mean of ln-PFHxS (x̅), the intercept b, and the target mean y) and results of BMD and BMDL are presented by BMR (e.g., ½ SD or 1 SD), study, and gender in Table D-17. Unrounded values of summary statistics from NHANES were used in the derivation of BMD and BMDL reported in Table D-17.

Table D-15 BMDs and BMDLs for effect of PFHxS (ng/mL) on elevated ALT using hybrid approach with cutoff for healthy population in Valenti et al. (2021)

BMR Extra Risk | Study | Gender | Cutoff C (U/L) | Percent Change (95% CI) | β (95% CI) ln-ALT(U/L) per ln (ng/mL) | Mean ln-ALT(U/L) ȳ | Standard Deviation ln ALT | Mean ln-PFHxS (ng/mL) x̅ | P(0) | P(d) | b = ȳ − βx̅ | Target mean ln-ALT(U/L) y | BMD (ng/mL) | BMDL (ng/mL)
5% | Kim et al. (2023b) | Male | 42 | 2.8 (−1.2, 7.0) | 0.0398 (−0.0174, 0.0976) | 3.28 | 0.46 | 0.67 | 16.1% | 20.3% | 3.25 | 3.35 | 12.52 | 3.14
5% | Kim et al. (2023b) | Female | 30 | 3.7 (−0.2, 7.8) | 0.0524 (−0.0029, 0.1084) | 2.96 | 0.41 | 0.12 | 14.0% | 18.3% | 2.95 | 3.03 | 4.51 | 2.22
10% | Kim et al. (2023b) | Male | 42 | 2.8 (−1.2, 7.0) | 0.0398 (−0.0174, 0.0976) | 3.28 | 0.46 | 0.67 | 16.1% | 24.5% | 3.25 | 3.42 | 64.47 | 6.58
10% | Kim et al. (2023b) | Female | 30 | 3.7 (−0.2, 7.8) | 0.0524 (−0.0029, 0.1084) | 2.96 | 0.41 | 0.12 | 14.0% | 22.6% | 2.95 | 3.09 | 14.91 | 4.18

Table D-16 BMDs and BMDLs for effect of PFHxS (ng/mL) on elevated ALT using hybrid approach with cutoff for whole cohort in Valenti et al. (2021)

BMR Extra Risk | Study | Gender | Cutoff C (U/L) | Percent Change (95% CI) | β (95% CI) ln-ALT(U/L) per ln (ng/mL) | Mean ln-ALT(U/L) ȳ | Standard Deviation ln ALT | Mean ln-PFHxS (ng/mL) x̅ | P(0) | P(d) | b = ȳ − βx̅ | Target mean ln-ALT(U/L) y | BMD (ng/mL) | BMDL (ng/mL)
5% | Kim et al. (2023b) | Male | 48 | 2.8 (−1.2, 7.0) | 0.0398 (−0.0174, 0.0976) | 3.28 | 0.46 | 0.67 | 10.1% | 14.6% | 3.25 | 3.38 | 26.17 | 4.38
5% | Kim et al. (2023b) | Female | 33 | 3.7 (−0.2, 7.8) | 0.0524 (−0.0029, 0.1084) | 2.96 | 0.41 | 0.12 | 9.5% | 14.0% | 2.95 | 3.05 | 6.97 | 2.79
10% | Kim et al. (2023b) | Male | 48 | 2.8 (−1.2, 7.0) | 0.0398 (−0.0174, 0.0976) | 3.28 | 0.46 | 0.67 | 10.1% | 19.1% | 3.25 | 3.46 | 212.78 | 11.29
10% | Kim et al. (2023b) | Female | 33 | 3.7 (−0.2, 7.8) | 0.0524 (−0.0029, 0.1084) | 2.96 | 0.41 | 0.12 | 9.5% | 18.5% | 2.95 | 3.13 | 29.82 | 6.02

Table D-17 BMDs and BMDLs for effect of PFHxS (ng/mL) on elevated ALT using BMR of half standard deviation (SD) or 1 SD

BMR Standard Deviation | Study | Gender | Percent Change (95% CI) | β (95% CI) ln-ALT(U/L) per ln (ng/mL) | Mean ln-ALT(U/L) ȳ | Standard Deviation ln ALT | Mean ln-PFHxS (ng/mL) x̅ | b = ȳ − βx̅ | Target mean ln-ALT(U/L) y | BMD (ng/mL) | BMDL (ng/mL)
0.5 | Kim et al. (2023b) | Male | 2.8 (−1.2, 7.0) | 0.0398 (−0.0174, 0.0976) | 3.28 | 0.46 | 0.67 | 3.25 | 3.51 | 665.24 | 18.90
0.5 | Kim et al. (2023b) | Female | 3.7 (−0.2, 7.8) | 0.0524 (−0.0029, 0.1084) | 2.96 | 0.41 | 0.12 | 2.95 | 3.16 | 57.69 | 8.54
1.0 | Kim et al. (2023b) | Male | 2.8 (−1.2, 7.0) | 0.0398 (−0.0174, 0.0976) | 3.28 | 0.46 | 0.67 | 3.25 | 3.74 | 226427 | 263.86
1.0 | Kim et al. (2023b) | Female | 3.7 (−0.2, 7.8) | 0.0524 (−0.0029, 0.1084) | 2.96 | 0.41 | 0.12 | 2.95 | 3.37 | 2955.6 | 68.51

The SAS code and results are provided by (Ru, 2024). For Kim et al. (2023b), the values of BMDLs using BMR of 1 SD were 263.86 ng/mL for men and 68.51 ng/mL for women. With this approach to deriving a POD, there is substantially more variability across PODs (as compared to the narrow range of BMDs and BMDLs across sexes, and BMR levels using the hybrid approach), which appears to be driven by the use of a much larger BMR than in the hybrid approach. The 1 SD shift in the distribution of ln-ALT using the standard deviation approach is illustrated using Figure D-4 below for women of Kim et al. (2023b), using the period of 1999–2018 in NHANES. Note that the 1 SD shift is equivalent to a 38% extra risk if using the hybrid approach with the cutoff for the healthy population of Valenti et al. (2021) and ½ SD shift is equivalent to 16% extra risk.

Figure D-4 The shift in the distribution using BMR of 1 SD for women of Kim et al. (2023b) compared to the shift using hybrid approach

#### NOAEL Approach

Although both the measurements of ALT and standards for “unhealthy” ALT vary considerably across locations and years and although it is difficult to pinpoint exactly how exceedances of a selected ULN should be interpreted, from a BMD modeling perspective, these ULN cutoffs can inform the selection of a NOAEL. The simplest option is to look at the distributions of ALT and PFHxS in the selected studies. In Kim et al. (2023b), there was a significant linear relationship between log_2_-PFHxS/ln-PFHxS and ln-ALT; thus, there is a basic correspondence between the distribution of PFHxS and the distribution of ALT in this population. Acknowledging that there are likely to be many other predictors of ALT in this population and that the correspondence is likely to be more complex than a simple one-to-one relationship, there still may be some information that can provide context as a NOAEL for comparison purposes with the other PODs.

Building on the argument that the 95th percentile of ALT in a population represents the cutoff for abnormal levels, then the 95%-percentile can represent the LOAEL and a lower percentile of ALT can represent a NOAEL. In Kim et al. (2023b), the 75th-percentile ALT values are below, but still near to, the selected Valenti et al. (2021) ULN cutoffs of 42 U/L in men and 30 U/L in women and thus, may be reasonably interpreted as a no effect level. The presented 95th percentile ALT values are far above the selected NOAEL, and the 50th percentile ALT values are well below the selected ULNs. The 75th percentile of ALT in Kim et al. (2023b) (see Table 2) was 33 U/L in men and 23 U/L in women. The 75th percentile of PFHxS in Kim et al. (2023b) (see Table 2) was 4.23 ng/mL in men and 2.71 ng/mL in women. For elevated ALT associated with PFHxS exposure, the NOAEL selected from the available epidemiological literature is 4.23 ng/mL in men and 2.71 ng/mL in women based on ALT data from Kim et al. (2023b).

#### Summary and Selection of the POD

In each of the three approaches, women were found to have lower PODs, and the final PODs for Human Equivalent Doses (HEDs) were computed just for women as the more sensitive sex.

Table D-18 shows the PODs for internal dose (mg/L) and the POD_HED_ (mg/kg-day) for men and women based on Kim et al. (2023b). The range of values is 9.10 × 10^⁻8^ (mg/kg-day) to 1.08 × 10^⁻5^ (mg/kg-day), wherein the lower limit is based on a BMR of 5% and the upper limit is based on the BMR of 1 SD, the latter of which was equivalent to an extra risk of 38% using the hybrid approach.

EPA selected a BMR of 10% extra risk for ALT concentrations greater than the 95th percentile in the healthy subset in Valenti et al. (2021) among women, based on the dose-response function from Kim et al. (2023b), highlighted in Table D-18; the corresponding POD_HED_ is 1.71 × 10^⁻7^ (mg/kg-day).

Table D-18 PODs from the preferred epidemiological study of hepatic effects considered for the derivation of PFHxS candidate toxicity values

Endpoint/study/confidence | Species/sex | POD type/model | POD internal dose (mg/L)^a^ | PODHED (mg/kg-d)^b^
Elevated ALT representing increased risk of liver effects; Kim et al. (2023b), Medium confidence | Human, female | BMDL_ER5,_ Hybrid with cutoff 30 | 2.22 × 10^⁻3^ | 9.10 × 10^⁻8^
Elevated ALT representing increased risk of liver effects; Kim et al. (2023b), Medium confidence | Human, female | BMDL_ER10,_ Hybrid with cutoff 30 | 4 .18 × 10^⁻3^ | 1.71 × 10^⁻7^
Elevated ALT representing increased risk of liver effects; Kim et al. (2023b), Medium confidence | Human, female | BMDL_ER5,_ Hybrid with cutoff 33 | 2.79 × 10^⁻3^ | 1.14 × 10^⁻7^
Elevated ALT representing increased risk of liver effects; Kim et al. (2023b), Medium confidence | Human, female | BMDL_ER10,_ Hybrid with cutoff 33 | 6.02 × 10^⁻3^ | 2.47 × 10^⁻7^
Elevated ALT representing increased risk of liver effects; Kim et al. (2023b), Medium confidence | Human, female | BMDL_1/2SD,_ Standard Deviation | 8.54 × 10^⁻3^ | 3.50 × 10^⁻7^
Elevated ALT representing increased risk of liver effects; Kim et al. (2023b), Medium confidence | Human, female | BMDL_1SD,_ Standard Deviation | 6.85 × 10^⁻2^ | 2.81 × 10^⁻6^
Elevated ALT representing increased risk of liver effects; Kim et al. (2023b), Medium confidence | Human, female | BMDL, NOAEL | 2.71 × 10^⁻3^ | 1.11 × 10^⁻7^
Elevated ALT representing increased risk of liver effects; Kim et al. (2023b), Medium confidence | Human, male | BMDL_ER5,_ Hybrid with cutoff 42 | 3.14 × 10^⁻3^ | 1.29 × 10^⁻7^
Elevated ALT representing increased risk of liver effects; Kim et al. (2023b), Medium confidence | Human, male | BMDL_ER10,_ Hybrid with cutoff 42 | 6.58 × 10^⁻3^ | 2.70 × 10^⁻7^
Elevated ALT representing increased risk of liver effects; Kim et al. (2023b), Medium confidence | Human, male | BMDL_ER5,_ Hybrid with cutoff 48 | 4.38 × 10^⁻3^ | 1.80 × 10^⁻7^
Elevated ALT representing increased risk of liver effects; Kim et al. (2023b), Medium confidence | Human, male | BMDL_ER10,_ Hybrid with cutoff 48 | 1.13 × 10^⁻2^ | 4.63 × 10^⁻7^
Elevated ALT representing increased risk of liver effects; Kim et al. (2023b), Medium confidence | Human, male | BMDL_1/2SD,_ Standard Deviation | 1.89 × 10^⁻2^ | 7.75 × 10^⁻7^
Elevated ALT representing increased risk of liver effects; Kim et al. (2023b), Medium confidence | Human, male | BMDL_1SD,_ Standard Deviation | 2.64 × 10^⁻1^ | 1.08 × 10^⁻5^
Elevated ALT representing increased risk of liver effects; Kim et al. (2023b), Medium confidence | Human, male | BMDL, NOAEL | 4.23 × 10^⁻3^ | 1.73 × 10^⁻7^

a Units for the POD internal dose have changed from Tables D-15, D-16, and D-17 where they are ng/mL (to match the concentrations reported in the studies) to mg/L because EPA uses units of mg/kg-d for POD_HEDS_. The conversion factor is (ng/mL)*(mg/10^6^ ng)*(1,000 mL/L).

b POD_HED_ = POD internal dose (mg/L) × 0.041 mL/kg-d × 10^⁻3^ L/mL, using the estimated clearance for men and women above age 50. (The effect is assumed relevant to older women, so the lower clearance value for men and older women is applied to PODs from both women and men.)

Between the two hybrid approaches, EPA chose the Valenti et al. (2021) 95th percentiles by the International Federation of Clinical Chemistry and Laboratory Medicine from the sub-cohort of healthy people screened for absence of viral hepatitis and metabolic syndrome. The use of these 95th percentile cutoffs is based on both a biological and statistical basis, per the Benchmark Dose Technical Guidance (U.S. EPA, 2012; Kavlock et al., 1995). EPA considered the BMR of 10% extra risk to be the most appropriate as ALT concentrations above the 95th percentile would predominantly be considered to be (minimally) adverse. EPA selected the POD_HED_ value of 1.71 × 10^⁻7^ (mg/kg-day) for elevated ALT as the candidate POD_HED_ for liver effects defined as increased risk of liver disease. Despite some uncertainties in the approach used to derive this value, the selected POD_HED_ is not substantially different from that derived using a NOAEL-based approach (i.e., 1.11 × 10^⁻7^ mg/kg-day), which mitigates concern about the uncertainties.

For comparison, the POD_HED_ based on women using Kim et al. (2023b) and a 5% BMR would be 9.10 × 10^⁻8^ (mg/kg-day); the POD_HED_ using the standard deviation approach for women using Kim et al. (2023b) and a BMR of 1 SD would be 2.81 × 10^⁻6^ (mg/kg-day); and the POD_HED_ using the NOAEL approach for women using Kim et al. (2023b) would be 1.11 × 10^⁻7^ (mg/kg-day). If the adversity of elevated ALT were judged to be more severe than (minimally) adverse based on the results of a 10-year longitudinal follow-up of Park et al. (2019) that found people with higher baseline ALT concentrations were at significantly increased risk for decompensated liver effects (cirrhosis), then the preferred POD_HED_ based on women using Kim et al. (2023b) and a 5% BMR would be 9.10 × 10^⁻8^.

## D.2 BENCHMARK DOSE MODELING RESULTS FROM ANIMAL STUDIES

### D.2.1 Benchmark Dose Modeling Approaches

The endpoints selected for benchmark dose (BMD) modeling are listed in Table D-19. The animal doses in the study were used in the BMD modeling and then converted to human equivalent doses (HEDs) using the PK model described in Section 3.1 of the main document; the BMD modeling results are presented in this appendix.

#### Modeling Procedure for Dichotomous Noncancer Data

BMD modeling of dichotomous noncancer data was conducted using EPA’s Benchmark Dose Software (BMDS, version 3.2). For these data, the Gamma, Logistic, Log-Logistic, Log-Probit, Multistage, Probit, Weibull, and Dichotomous Hill models available within the software were fit using a benchmark response (BMR) of 10% extra risk. The Multistage model is run for all polynomial degrees up to n – 2, where n is the number of dose groups including control. Adequacy of model fit was judged on the basis of χ^2^ goodness -of -fit p-value (p > 0.1), scaled residuals at the data point (except the control) closest to the predefined benchmark response (absolute value <2.0), and visual inspection of the model fit. Among all models providing adequate fit, the benchmark dose lower confidence limit (BMDL) from the model with the lowest Akaike’s information criterion (AIC) was selected as a potential POD when BMDL values were sufficiently close (within threefold). Otherwise, the lowest BMDL was selected as a potential POD.

#### Modeling Procedure for Continuous Noncancer Data

BMD modeling of continuous noncancer data was conducted using EPA’s Benchmark Dose Software (BMDS, version 3.2). For these data, the Exponential, Hill, Polynomial, and Power models available within the software are fit using a BMR of 1 standard deviation (SD) when no toxicological information was available to determine an adverse level of response. When toxicological information was available, the BMR was based on relative deviation, as outlined in the Benchmark Dose Technical Guidance (U.S. EPA, 2012). An adequate fit is judged on the basis of χ^2^ goodness of fit p-value (p > 0.1), scaled residuals at the data point (except the control) closest to the predefined benchmark response (absolute value <2.0), and visual inspection of the model fit. In addition to these three criteria for judging adequacy of model fit, a determination is made on whether the variance across dose groups is homogeneous. If a homogeneous variance model is deemed appropriate based on the statistical test provided by BMDS (i.e., Test 2), the final BMD results are estimated from a homogeneous variance model. If the test for homogeneity of variance is rejected (p < 0.05), the model is run again, while modeling the variance as a power function of the mean to account for this nonhomogeneous variance.

Among all models providing adequate fit, the BMDL from the model with the lowest AIC was selected as a potential POD when BMDL estimates differed by less than threefold. When BMDL estimates differed by greater than threefold, the model with the lowest BMDL was selected to account for model uncertainty.

#### Data Used for Modeling

The source of the data used for modeling endpoints from animal studies is provided in Table D-19. These data also are included in full in the tables below.

Table D-19 Sources of data used in benchmark dose modeling of PFHxS endpoints from animal studies

Endpoint | Reference | HAWC link
Endocrine effects
↓ Total T4 – M | NTP (2018) | https://hawcprd.epa.gov/ani/endpoint/100508242/
↓ Total T4 – C; F1 (PND16/17) | Ramhøj et al. (2018); [underlined: MULTI-GEN] | https://hawcprd.epa.gov/ani/endpoint/100508634/
↓ Total T4 – C; F1 (PND22) | Ramhøj et al. (2018); [underlined: MULTI-GEN] | https://hawcprd.epa.gov/ani/endpoint/100508636/
↓ T3 – M | NTP (2018) | https://hawcprd.epa.gov/ani/endpoint/100508240/
↓ T3 – C; F1 PND 16/17 | Ramhøj et al. (2020) | https://hawcprd.epa.gov/ani/endpoint/100515830/

##### Decreased Total T4 in Male Rats (NTP, 2018)

Table D-20 Dose-response data for decreased total T4 in male rats NTP (2018)

Dose (mg/kg-d) | n | Mean (µg/dL) | Standard Deviation
0 | 10 | 4.24 | 0.724
0.625 | 10 | 2.39 | 0.247
1.25 | 10 | 1.70 | 0.183
2.5 | 10 | 1.47 | 0.221
5 | 10 | 1.54 | 0.294
10 | 10 | 1.66 | 0.152

Table D-21 Benchmark dose results for decreased total T4 in male rats―nonconstant variance (NCV)^a^, BMR = 1 standard deviation NTP (2018)

Models | Test 3 (p-Value) | 1 standard deviation | | Goodness of fit (p-value) | AIC | BMDS classification^b^ | BMDS notes
Models | Test 3 (p-Value) | BMD | BMDL | Goodness of fit (p-value) | AIC | BMDS classification^b^ | BMDS notes
Exponential 3; (NCV―normal) | 0.0785 | 38.2733 | 20.7157 | <0.0001 | 119.8009 | Questionable | Goodness of fit p-value < 0.1; BMD higher than maximum dose; BMDL higher than maximum dose; \|Residual at control\| > 2; Modeled control response std. dev. >\|1.5\| actual response std. dev.
Exponential 5; (NCV―normal) | 0.0785 | 0.2033 | 0.1017 | 0.1740 | 27.1215 | Viable - Recommended | Lowest AIC; BMD 3× lower than lowest non-zero dose; BMDL 3× lower than lowest non-zero dose
Hill; (NCV―normal) | 0.0785 | 0.3445 | 0.2250 | 0.1391 | 27.5693 | Viable - Alternate
Polynomial (3 degree); (NCV―normal) | 0.0785 | 26.5007 | 17.8787 | <0.0001 | 123.9662 | Questionable | Goodness of fit p-value < 0.1; BMD higher than maximum dose; BMDL higher than maximum dose; \|Residual at control\| > 2; Modeled control response std. dev. >\|1.5\| actual response std. dev.
Polynomial (2 degree); (NCV―normal) | 0.0785 | 27.4743 | 18.3063 | <0.0001 | 121.8350 | Questionable | Goodness of fit p-value < 0.1; BMD higher than maximum dose; BMDL higher than maximum dose; \|Residual at control\| > 2; Modeled control response std. dev. >\|1.5\| actual response std. dev.
Power; (NCV―normal) | 0.0785 | 27.2619 | 18.2844 | <0.0001 | 121.8478 | Questionable | Goodness of fit p-value < 0.1; BMD higher than maximum dose; BMDL higher than maximum dose; \|Residual at control\| > 2; Modeled control response std. dev. >\|1.5\| actual response std. dev.
Linear; (NCV―normal) | 0.0785 | 27.4743 | 18.3066 | <0.0001 | 121.8350 | Questionable | Goodness of fit p-value < 0.1; BMD higher than maximum dose; BMDL higher than maximum dose; \|Residual at control\| > 2; Modeled control response std. dev. >\|1.5\| actual response std. dev.

a Data fails constant variance assumption (Test 2 p-value < 0.0001).

b ”Classification” column denotes whether a model can be considered for model selection purposes. See BMDS User Guide: https://www.epa.gov/bmds.

Figure D-5 Graph of dose response data and curve for the exponential 5 model for decreased total T4 in male rats NTP (2018)

X-axis is dose (mg/kg-d) and y-axis is level of total T4 (µg/dL).

##### Decreased Total T4 in Rats (F1) on PND16/17 Ramhøj et al. (2018)

Table D-22 Dose-response data for decreased total T4 in rats (F1) on PND16/17 Ramhøj et al. (2018)

Dose (mg/kg-d) | n | Mean (µg/dL) | Standard Deviation
0 | 14 | 74.49 | 6.642
0.05 | 14 | 77.23 | 13.270
5 | 14 | 50.38 | 6.642
25 | 14 | 40.11 | 6.616

Table D-23 Benchmark dose results for decreased total T4 in rats (F1) on PND16/17 ― non-constant variance (NCV)^a^, BMR = 1 standard deviation Ramhøj et al. (2018)

Models | Test 3 (p-Value) | 1 standard deviation | | Goodness of fit (p-value) | AIC | BMDS classification^b^ | BMDS notes
Models | Test 3 (p-Value) | BMD | BMDL | Goodness of fit (p-value) | AIC | BMDS classification^b^ | BMDS notes
Exponential 3; (NCV―normal) | 0.0476 | - | - | - | - | Unusable | BMD computation failed
Exponential 5; (NCV―normal) | 0.0476 | 3.6417 | 0.9108 | <0.0001 | 405.3204 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05); BMD/BMDL ratio > 3; Modeled control response std. dev. >\|1.5\| actual response std. dev.; d.f.=0, saturated model; (Goodness of fit test cannot be calculated)
Hill; (NCV―normal) | 0.0476 | 3.1807 | 0.5370 | <0.0001 | 405.3204 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05); BMD/BMDL ratio > 3; Modeled control response std. dev. >\|1.5\| actual response std. dev.; d.f.=0, saturated model; (Goodness of fit test cannot be calculated)
Polynomial (3 degree); (NCV―normal) | 0.0476 | 11.0970 | 8.5972 | <0.0001 | 435.2131 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05); Goodness of fit p-value < 0.1; \|Residual for Dose Group Near BMD\| > 2; Modeled control response std. dev. >\|1.5\| actual response std. dev.
Polynomial (2 degree); (NCV―normal) | 0.0476 | 11.1603 | 8.5965 | <0.0001 | 435.2092 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05); Goodness of fit p-value < 0.1; \|Residual for Dose Group Near BMD\| > 2; Modeled control response std. dev. >\|1.5\| actual response std. dev.
Power; (NCV―normal) | 0.0476 | 11.0079 | 8.5894 | <0.0001 | 435.2246 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05); Goodness of fit p-value < 0.1; \|Residual for Dose Group Near BMD\| > 2; Modeled control response std. dev. >\|1.5\| actual response std. dev.
Linear; (NCV―normal) | 0.0476 | 11.1598 | 8.5966 | <0.0001 | 435.2092 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05); Goodness of fit p-value < 0.1; \|Residual for Dose Group Near BMD\| > 2; Modeled control response std. dev. >\|1.5\| actual response std. dev.

a Data fails both constant variance and non-constant variance assumptions (Test 2 and Test 3 p-value < 0.05).

b “Classification” column denotes whether a model can be considered for model selection purposes. See BMDS User Guide: https://www.epa.gov/bmds.

Figure D-6 Graph of dose response data for decreased total T4 in rats (F1) on PND16/17 Ramhøj et al. (2018)

X-axis is dose (mg/kg-d) and y-axis is level of total T4 (µg/dL).

##### Decreased Total T4 in Rats (F1) on PND22 Ramhøj et al. (2018)

Table D-24 Dose-response data for decreased T4 in rats (F1) on PND22 Ramhøj et al. (2018)

Dose (mg/kg-d) | n | Mean (µg/dL) | Standard Deviation
0 | 20 | 37.70 | 7.165
0.05 | 13 | 41.64 | 13.467
5 | 13 | 27.94 | 8.619
25 | 13 | 10.85 | 2.308

Table D-25 Benchmark dose results for decreased total T4 in rats (F1) on PND22 ― non-constant variance (NCV)^a^, BMR = 1 standard deviation Ramhøj et al. (2018)

Models | Test 3 (p-Value) | 1 standard deviation | | Goodness of fit (p-value) | AIC | BMDS classification^b^ | BMDS notes
Models | Test 3 (p-Value) | BMD | BMDL | Goodness of fit (p-value) | AIC | BMDS classification^b^ | BMDS notes
Exponential 3; (NCV―normal) | 0.0932 | - | - | - | - | Unusable | BMD computation failed
Exponential 5; (NCV―normal) | 0.0932 | 5.0219 | 3.2645 | NA | 407.6268 | Questionable | d.f.=0, saturated model; (Goodness of fit test cannot be calculated)
Hill; (NCV―normal) | 0.0932 | 5.0226 | 3.1477 | NA | 407.6268 | Questionable | d.f.=0, saturated model; (Goodness of fit test cannot be calculated)
Polynomial (3 degree); (NCV―normal) | 0.0932 | 9.8034 | 8.0456 | 0.0308 | 407.1171 | Questionable | Goodness of fit p-value < 0.1
Polynomial (2 degree); (NCV―normal) | 0.0932 | 9.8034 | 8.0456 | 0.0308 | 407.1171 | Questionable | Goodness of fit p-value < 0.1
Power (NCV―normal) | 0.0932 | 9.8169 | 8.0463 | 0.0308 | 407.1174 | Questionable | Goodness of fit p-value < 0.1
Linear; (NCV―normal) | 0.0932 | 9.8034 | 8.0456 | 0.0308 | 407.1171 | Questionable | Goodness of fit p-value < 0.1

a Data cannot be modeled under constant variance assumption (Test 2 p-value < 0.0001) and failed to yield a viable model under the non-constant variance assumption.

b “Classification” column denotes whether a model can be considered for model selection purposes. See BMDS User Guide: https://www.epa.gov/bmds.

Figure D-7 Graph of dose response data for decreased total T4 in rats (F1) on PND22 Ramhøj et al. (2018)

X-axis is dose (mg/kg-d) and y-axis is level of total T4 (µg/dL)

##### Decreased T3 in Male Rats (NTP, 2018)

Table D-26 Dose-response data for decreased T3 in male rats NTP (2018)

Dose (mg/kg-d) | n | Mean (µg/dL) | Standard Deviation
0 | 10 | 85.18 | 18.139
0.625 | 10 | 66.21 | 13.288
1.25 | 10 | 58.67 | 9.066
2.5 | 10 | 54.25 | 7.302
5 | 10 | 52.50 | 4.494
10 | 10 | 56.83 | 12.519

Table D-27 Benchmark dose results for decreased T3 in male rats ― non-constant variance (NCV)^a^, BMR = 1 standard deviation NTP (2018)

Models | Test 3 (p-Value) | 1 standard deviation | | Goodness of fit (p-value) | AIC | BMDS classification^b^ | BMDS notes
Models | Test 3 (p-Value) | BMD | BMDL | Goodness of fit (p-value) | AIC | BMDS classification^b^ | BMDS notes
Exponential 3; (NCV―normal) | 0.1919 | 11.5010 | 5.5516 | <0.0001 | 494.9950 | Questionable | Goodness of fit p-value < 0.1; BMD higher than maximum dose; \|Residual at control\| > 2
Exponential 5; (NCV―normal) | 0.1919 | 0.6069 | 0.2639 | 0.0652 | 461.6615 | Questionable | Goodness of fit p-value < 0.1
Hill; (NCV―normal) | 0.1919 | 0.6148 | 0.2594 | 0.0571 | 461.9241 | Questionable | Goodness of fit p-value < 0.1
Polynomial (3 degree); (NCV―normal) | 0.1919 | 9.9054 | 6.5375 | <0.0001 | 496.3957 | Questionable | Goodness of fit p-value < 0.1; \|Residual at control\| > 2
Polynomial (2 degree); (NCV―normal) | 0.1919 | 12.7336 | 6.8293 | <0.0001 | 495.9569 | Questionable | Goodness of fit p-value < 0.1; BMD higher than maximum dose; \|Residual at control\| > 2
Power (NCV―normal) | 0.1919 | 10.9337 | 6.6985 | <0.0001 | 496.1460 | Questionable | Goodness of fit p-value < 0.1; BMD higher than maximum dose; \|Residual at control\| > 2
Linear; (NCV―normal) | 0.1919 | 12.9196 | 6.8265 | <0.0001 | 495.9600 | Questionable | Goodness of fit p-value < 0.1; BMD higher than maximum dose; \|Residual at control\| > 2

a Data cannot be modeled under constant variance assumption (Test 2 p-value < 0.001) and failed to yield a viable model under the non-constant variance assumption.

b “Classification” column denotes whether a model can be considered for model selection purposes. See BMDS User Guide: https://www.epa.gov/bmds

Figure D-8 Figure D 4. Graph of dose response data for decreased T3 in male rats NTP (2018)

X-axis is dose (mg/kg-d) and y-axis is level of T3 (µg/dL).

##### Decreased T3 in Rats (F1) on PND16/17 Ramhøj et al. (2018)

Table D-28 Dose-response data for decreased T3 in rats (F1) on PND16/17 Ramhøj et al. (2018)

Dose (mg/kg-d) | n | Mean (µg/dL) | Standard Deviation
0 | 14 | 99.91 | 13.576
0.05 | 14 | 102.81 | 5.986
5 | 14 | 92.91 | 8.980
25 | 14 | 83.81 | 11.993

Table D-29 Benchmark dose results for decreased T3 in rats (F1) on PND16/17 ― non-constant variance (NCV)^a^, BMR = 1 standard deviation Ramhøj et al. (2018)

Models | Test 3 (p-Value) | 1 standard deviation | | Goodness of fit (p-value) | AIC | BMDS classification^b^ | BMDS notes
Models | Test 3 (p-Value) | BMD | BMDL | Goodness of fit (p-value) | AIC | BMDS classification^b^ | BMDS notes
Exponential 3; (NCV―normal) | 0.0072 | 15.0946 | 10.7198 | 0.3754 | 460.1321 | Unusable | Non-constant variance test failed (Test 3 p-value < 0.05)
Exponential 5; (NCV―normal) | 0.0072 | 5.4845 | 3.0450 | 0.2891 | 462.1492 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05)
Hill; (NCV―normal) | 0.0072 | 5.6767 | 2.4456 | NA | 464.1008 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05); d.f.=0, saturated model; (Goodness of fit test cannot be calculated)
Polynomial (3 degree); (NCV―normal) | 0.0072 | - | - | - | - | Questionable | BMD computation failed
Polynomial (2 degree); (NCV―normal) | 0.0072 | 15.8478 | 11.6039 | 0.3438 | 460.3533 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05)
Power; (NCV―normal) | 0.0072 | 15.8478 | 11.6039 | 0.3438 | 460.3533 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05)
Linear; (NCV―normal) | 0.0072 | 15.8478 | 11.6039 | 0.3438 | 460.3533 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05)

a Data fails both constant variance and non-constant variance assumptions (Test 2 and Test 3 p-value < 0.05).

b “Classification” column denotes whether a model can be considered for model selection purposes. See BMDS User Guide: https://www.epa.gov/bmds

Figure D-9 Graph of dose response data for decreased T3 in rats (F1) on PND16/17 Ramhøj et al. (2018)

X-axis is dose (mg/kg-d) and y-axis is level of T3 (µg/dL).

5 Budtz-Jørgensen and Grandjean (2018a) computed BMDs and BMDLs using a BMR of 5% decrease in the log_2_(antibody concentrations). Their formula, BMD = log_2_(1-BMR)/β, can simply be reversed to solve for β = log_2_(1-BMR)/BMD. For negative dose-response where more exposure results in lower antibody concentration, the BMDL is based on the lower bound of β, (β_LB_). Thus, the β_LB_ = log_2_(1-BMR)/BMDL. The SE(β) = (β - β_LB_)/1.645. The p-value is the two-sided probability that Z <= SE(β)/β.

6 Pooled variance for tetanus in 5-year-olds = [(502-1)(1.74)^2+ (298-1)(1.17)^2]/[502+298-2] = 2.41. The pooled SD is the square root of 2.41 which is 1.55 log_2_(IU/mL).

7 Pooled variance for tetanus in 5-year-olds = [(502-1)(1.74)^2+ (298-1)(1.17)^2]/[502+298-2] = 2.41. The pooled SD is the square root of 2.41 which is 1.55 log_2_(IU/mL).

8 While the explicit application of the hybrid approach is not commonly used in IRIS dose/concentration/exposure-response analyses, the more commonly used SD-definition of the BMR for continuous data is simply one specific application of the hybrid approach. The SD-definition of the BMR assumes that the cut-off for adversity is the 1.4th percentile of a normally distributed response and that shifting the mean of that distribution by one standard deviation approximates an extra risk of 10%.

9 This date range was selected to utilize all available NHANES data that cover the sampling periods of Kim et al. (2023b). The study population of Kim et al. (2023b) was a sub-population of the KoNEHS cycle 3, 2015–2017.

10 Concentration data are generally assumed to be log-normally distributed, and Kim et al. (2023b) applied natural log transformations of ALT prior to deriving the dose-response functions.

11 Sex-specific results are in the Kim et al. (2023b) Supplemental.

12 The study population of (Kim et al., 2023b) was a sub-population of the KoNEHS, the biomonitoring program in South Korea adult (age ≥ 19) population. Participants with self-reported history of liver diseases including hepatitis B, hepatitis C, liver cirrhosis, and liver cancer were excluded. The median (IQR) of PFHxS exposure of the study population is 2.29 ng/mL (IQR: 1.42–3.45 ng/mL).

13 Percentage increase = (e^β^−1)*100) see Kim et al. (2023b).