# APPENDIX C SUPPLEMENTAL APPROACHES AND DATA ANALYSES

## C.1 PFAS CO-EXPOSURE CONSIDERATIONS AND META-ANALYSIS OF PFHXS EFFECTS ON BIRTH WEIGHT

As noted in the polyfluoroalkyl substances (PFAS) protocol, the potential for confounding by co-occurring PFAS to bias effect estimates is a concern in epidemiological studies despite a lack of scientific consensus on how best to address PFAS co-exposures (and other co-occurring contaminants) especially those exposures that may derive from different sources. The potential for confounding across PFAS is incorporated in individual study evaluations and assessed across studies in evidence syntheses and in the characterizations of the strength of evidence. For other covariates like glomerular filtration rate, in general, more confidence was placed in studies that adjusted for pregnancy hemodynamics, or if they considered this potential source of bias by sampling PFAS levels earlier in pregnancy. More details on the considerations of the potential effect of PFAS co-exposures and pregnancy hemodynamics follow.

### C.1.1 Confounding Directionality and PFAS Co-exposure Statistical Approaches

A source of uncertainty in the epidemiological database was the potential for confounding by other PFAS (and other co-occurring contaminants). Co-occurring PFAS that are actual confounders (i.e., associated with both the PFAS of interest and the outcome, but not an intermediate in the causal pathway between the two) would be considered positive confounders if their effect estimate with the endpoint of interest is in the same direction as the main primary PFAS of interest. In this example, such PFAS are considered positive confounders if their effect estimate with the endpoint of interest is in the same direction as the primary PFAS of interest. If positive confounders are not accounted for in the epidemiological study design or analysis phase, the anticipation is that any resultant bias would be away from the null.

Statistical approaches can help address the challenges of evaluating the effects of numerous PFAS that may be present in the environment and estimated via different biomarkers and other exposure measures. For example, multi-pollutant models (i.e., those that adjust for at least one co-exposure) can theoretically provide an estimate of the independent association for specific pollutants with the endpoint of interest by controlling for the independent effect of one or more co-exposures, thereby removing the potential confounding bias (assuming proper functional forms of and limited measurement error related to the confounding variables). However, under certain circumstances, when highly correlated co-exposures are included in the same model, controlling for one co-exposure can potentially amplify the potential confounding bias of another confounder rather than removing it (Weisskopf et al., 2018). This may be especially problematic when confounding is present and simultaneously adjusted PFAS exposures come from different exposure sources. Dimension-reducing statistical approaches (e.g., principal component analysis and penalized modeling based on elastic net regression) are increasingly being used for screening large groups of chemical classes and help to prioritize specific mixtures. However, as noted by Meng et al. (2018), these approaches might be better suited as “prediction models to screen for a wide range of chemicals from different sources, and the interpretation of results might become less straightforward due to the necessary standardization of exposure values.” These regression model outputs also do not provide confidence intervals (CIs), which precludes evaluations of precision. Given these interpretation difficulties and potential for co-exposure amplification bias, there is uncertainty which statistical approach best represents independent effects of specific pollutants within complex PFAS mixtures.

In the main developmental epidemiological syntheses, the evaluation of between-study heterogeneity is based on single pollutant models to increase comparability of available data. An evaluation of single-pollutant (i.e., PFHxS alone with other confounders adjusted for) models and other approaches are detailed below. The objective herein is to assess whether there is any direct evidence for confounding in the studies comparing multi-pollutant (mutually adjusted for other PFAS and other confounders) and single-pollutant model results under the assumption that multi-pollutant models may provide a better reflection of the underlying risk in the absence of any co-amplification bias. Additional objectives of this Appendix were to consider the potential for confounding by examining the strength of associations between co-occurring PFAS as well as those between each PFAS and the primary endpoint of interest (e.g., birth weight-related measures).

### C.1.2 PFAS Co-exposure Correlations with PFHxS

In general, the stronger the correlation or association observed between co-exposures, and the larger the associations between the co-exposure and endpoints such as fetal growth restriction, the more concern there would be for potential confounding. A preliminary analysis of 22 studies in the inventory informs Table C-1, which illustrates the direction and magnitude of the correlations between PFAS co-exposures in the PFHxS studies that examined these measures. While it shows that some PFAS co-occur with PFHxS (as expected given some similar anticipated sources), it also illustrates that the magnitude of these relationships can vary across studies. For example, with the exception of two studies for which correlations ranged from 0.30 to 0.34, most studies showed moderate or high correlations of PFHxS with PFOA and PFOS (range: 0.47–0.75). PFHxS was consistently weakly or moderately correlated with both PFDA and PFNA in all of these studies (range: 0.22–0.51). These data suggest that among the other PFAS that have been evaluated, PFOS, and to a lesser extent, PFOA, might be the co-exposures of most concern in many study settings. The stronger correlations between PFHxS and PFOS is unsurprising because, of these chemicals, PFOS shares the greatest structural similarity with PFHxS. In addition to the impact of the structural similarity on the physico-chemical properties that determine disposition of the chemicals in the environment, these chemicals may also occur together due to their co-production in the manufacturing process (Boucher et al., 2019; 3M, 1999). Similarly, although co-occurrence data may be unavailable, other sulfonated PFAS that are unmeasured or less well characterized in biomarkers may likewise represent potential co-exposures of concern.

Table C-1 PFAS correlation coefficients in nine mutually adjusted PFAS studies

Reference | Study confidence | Correlations with PFHxS
| | PFOS | PFOA | PFNA | PFDA
Ashley-Martin et al. (2017) | High | 0.55 | 0.47
Luo et al. (2021) | High | 0.01 | 0.02 | −0.04 | −0.03
Manzano-Salgado et al. (2017) | High | 0.56 | 0.40 | 0.36
Shoaff et al. (2018) ^a^ | High | ~0.6 | ~0.4 | ~0.3 | ~0.2
Starling et al. (2017) | High | 0.65 | 0.61 | 0.45 | 0.27
Hamm et al. (2010) | Medium | 0.54 | 0.55
Lenters et al. (2016) | Medium | 0.34 | 0.34 | 0.22 | 0.36
Meng et al. (2018) | Medium | 0.30 | 0.33 | 0.28
Callan et al. (2016) | Low | 0.75 | 0.71 | 0.51 | 0.44

a Shoaff et al. (2018) Pearson correlation coefficients ranged from 0.32 (PFNA and PFHxS) to 0.60 (PFOA and PFOS). The estimated correlation coefficients above are based on their related publication (Woods et al., 2017); thus, this may slightly over-estimate the PFDA and PFNA correlation given the initial range provided by Shoaff.

### C.1.3 PFHxS and PFAS Co-exposure Study Results

Nine of the PFHxS studies that were evaluated examined PFAS co-exposures including one low confidence (Callan et al., 2016), three medium confidence (Meng et al., 2018; Lenters et al., 2016; Hamm et al., 2010), and five high confidence studies (Starling et al., 2017; Shoaff et al., 2018; Manzano-Salgado et al., 2017; Luo et al., 2021; Ashley-Martin et al., 2017). The studies by Hamm et al. (2010) and Luo et al. (2021) did not provide both single-pollutant and multi-pollutant model results for the continuous exposures of interest; this lack of a direct comparison precluded further evaluations of the potential confounding by co-occurring PFAS in that study. The results for the seven other studies based on continuous PFHxS unit changes are compared and summarized below to assess whether any patterns of evidence for larger associations with other PFAS occurred and/or any direct evidence for confounding in the mutually adjusted PFAS studies examining mean birth weight given the primary focus on this endpoint (Table C-2). Two of these studies (Starling et al., 2017; Lenters et al., 2016) examined PFAS co-exposures through elastic net regression, while the remaining studies performed multi-pollutant modeling using ordinary least squares regression.

As shown in Table C-2, Callan et al. (2016) found large mean birth weight deficits (β = −72 g; 95% CI: −194, 50) in their single-pollutant model of PFHxS, which became stronger (39% increase) following adjustment only for perfluoroundecanoic acid (β = −100 g; 95% CI: −221, −22). Meng et al. (2018) reported nonsignificant deficits (β = −12.4 g; 95% CI: −46.2, 21.4) in a single-pollutant PFHxS model, which became stronger (30% increase) upon adjustment of PFOS, PFOA, and PFNA in their multi-pollutant model (β = −16.4 g; 95% CI: −61.0, 28.1). Starling et al. (2017) reported largely null findings for PFHxS based on either single-pollutant or multi-pollutant models and this PFAS was not selected based on their elastic net regression. Lenters et al. (2016) reported null results for PFHxS in both their single-pollutant model and their elastic net regression of mutually adjusted PFAS with only PFOA retained in the latter model. Shoaff et al. (2018) reported that their marginally significant single-pollutant PFHxS birth weight z-score was attenuated and became more imprecise upon multi-pollutant adjustment. Meng et al. (2018) reported largely null results for PFHxS in single-pollutant models, whereas a nonsignificant increase in mean birth weight was seen upon multi-pollutant adjustment for PFOS, PFOA, PFNA, perfluoroheptane sulfonic acid (PFHpS), and PFDA.

Among these limited studies, there were no consistent patterns detected in the birth weight data for PFHxS following mutual adjustment for other correlated PFAS. For example, two of the five studies that reported birth weight deficits in single-pollutant models were strengthened in similar fashion (30%–39%) following statistical adjustment for other PFAS. In contrast, associations in two other studies were attenuated and another study went from an overall mean decreased birthweight to increased birthweight following adjustment. The other two studies were null in both single and multi-pollutant models. There were also no clear patterns of larger associations for other PFAS examined in these studies (data not shown). Thus, strong, and consistent evidence of confounding by other PFAS is not demonstrated in these studies, which is also supported by the lack of differences in the PFHxS-stratified pooled estimates evaluated in the meta-analysis conducted by US EPA (Ru et al., 2024). If confounding were present, there would likely be more variability detected across studies and strata given the variable correlations noted above. While there is still uncertainty due to reported correlations between PFHxS and some PFAS (e.g., PFOS), based on the available evidence, it seems unlikely that the consistency of birth weight deficits demonstrated from (categorical and continuous results) in the full set of 27 PFHxS studies examined here can be fully attributed to confounding by PFAS co-exposures.

Table C-2 Impact of co-exposure exposure adjustment on birth weight results (change in mean birth weight or birth weight Z-scores) per unit change (ng/mL) in PFHxS levels

Reference | Study confidence | Birth weight measure | Single-PFAS model results with 95% CIs | Multi-PFAS results with 95% CIs | Elastic net regression results | Effect of adjustment on PFHxS birth weight results | PFAS adjustments
Ashley-Martin et al. (2017) | High | Birth Weight z-scores | 0.08 (−0.12, 0.20)^a^ | 0.04 (−0.13, 0.21)^a^ | N/A | Slightly Attenuated | PFOS, PFOA
Shoaff et al. (2018) | High | Birth Weight z-scores^b^ | −0.08 (−0.18, 0.01)^a^ | −0.05 (−0.17, 0.06)^a^ | N/A | Slightly Attenuated | PFOS, PFOA, PFNA
Manzano-Salgado et al. (2017) | High | Mean Birth Weight | −12.4 (−46.2, 21.4) | −16.4 (−61.0, 28.1) | N/A | Slightly Strengthened | PFOS, PFOA, PFNA
Starling et al. (2017) | High | Mean Birth Weight | −13.5 (−50.7, 23.7) | 11.5 (−38.9, 61.9) | N/S | Changed direction from Negative to Positive | PFOS, PFOA, PFNA, PFDeA
Luo et al. (2021) | High | Mean Birth Weight | −12.5 (−106.8, 81.8) | −3.0 (−50.8, 43.6) | N/A | Very Attenuated | PFOS, PFOA, PFNA, PFUnDA, PFDoDA, PFDA, PFBS, PFTrDA, PFBA, 8:2 Cl-PFESA, 6:2 Cl-PFESA
Lenters et al. (2016) | Medium | Mean Birth Weight | −19.1 (−40.7, 2.3) | N/A | N/S | Attenuated | PFOS, PFOA, PFNA, PFUnDA, PFDoDA, PFDA
Meng et al. (2018) | Medium | Mean Birth Weight | 1.7 (−40.8, 44.3) | 25.0 (−10.1, 60.1) | N/A | Changed from Null to Positive | PFOS, PFOA, PFNA, PFDA, PFHpS
Callan et al. (2016) | Low | Mean Birth Weight | −72 (−194, 50) | −100 (−221, 22) | N/A | Strengthened | PFUnDA

Abbreviations: N/A: not available; N/S: PFAS not selected in final elastic net regression model. PFUnDA: perfluoroundecanoic acid; PFDeA: perfluorodecanoic acid; PFDoDA: perfluorododecanoic acid; PFHpS: perfluoroheptanesulfonic acid.

a The Ashley-Martin et al. (2017) study BWT z-score results are per log-10 unit increases and the Shoaff et al. (2018) study BWT z-score results are per a log-2 increase (i.e., a doubling of PFHxS exposure); all other studies presented here were for each ln-unit increase based on original results from publication or EPA re-expressions.

b The mean birth weight result for the single-pollutant model in Shoaff et al. (2018) was −13.4 grams (95% CI: −35.9, 9.1) per each 1 ng/mL increase (JR Shoaff Personal Communication, 10-19-18 (Shoaff, 2018)).

### C.1.4 Pregnancy Hemodynamics Background

Pregnancy-related hemodynamic changes that occur during pregnancy (e.g., increased blood plasma volume due to decreased mean arterial pressure, increased cardiac output, and systemic vasodilation (Sanghavi and Rutherford, 2014; Sagiv et al., 2018; Chapman et al., 1998)) are complex and can lead to challenges in data interpretability when timing of PFAS sampling differs within and across studies. These changes could lead to lower PFAS levels in plasma, due to dilution and increased renal filtration. A decrease in PFAS levels has been noted in serial measurements for most of some PFAS during pregnancy, namely PFOA, PFOS, and PFNA (Glynn et al., 2012; Chen et al., 2021). These hemodynamic changes have been proposed as a potential source of bias for associations between different PFAS and neonatal and early childhood growth measures, which is suggested by the association between glomerular filtration rate (GFR), a marker of renal function and, indirectly, of plasma volume expansion, and fetal growth independent of gestational age and other maternal covariates (Morken et al., 2014; Gibson, 1973). Because PFNA concentration in serum is expected to decrease during pregnancy due to plasma volume expansion, increased renal excretion, and transplacental transfer, time windows earlier in pregnancy prior to this decrease may reflect the largest insult to a developing fetus. Potential confounding is one possible explanation for the effects of pregnancy hemodynamics, but Steenland et al. (2018a) also proposed that GFR may lead to reverse causality if increased fetal growth leads to increased maternal blood expansion and glomerular filtration rate. These potential sources of bias are anticipated to be of greater concern when maternal serum PFAS samples are collected later in pregnancy. Therefore, as part of the study quality evaluations, more confidence was placed in studies that adjusted for pregnancy hemodynamics or if they considered this potential source of bias by sampling PFAS levels earlier in pregnancy.

Only three of the 21 PFHxS studies examined in the Developmental Effects section were able to analyze maternal hemodynamic data such as GFR and albumin (i.e., a marker of plasma volume expansion). None of these studies showed evidence of substantial confounding of the associations between PFAS and fetal growth following statistical adjustment for GFR (Manzano-Salgado et al., 2019; Gyllenhammar et al., 2018b), or for GFR and albumin (Sagiv et al., 2018). Although early pregnancy measures may limit this potential source of bias, the first trimester sampling of plasma albumin and GFR in two of these studies (Sagiv et al., 2018; Manzano-Salgado et al., 2019) may not be best-suited to examine potential confounding if the sample timing did not fully reflect pregnancy-related hemodynamic changes. However, the study by (Gyllenhammar et al., 2018b) with postpartum samples along with another measurement of PFOA and PFOS based on mid-pregnancy samples (Whitworth et al., 2012) have also shown no evidence of confounding by albumin or GFR levels. These data run counter to meta-analyses for both PFOA (Steenland et al., 2018a) and PFOS (Dzierlenga et al., 2020), which have detected larger birth weight deficits for later trimester sampling (e.g., beyond trimester one) compared with early periods. To examine whether the overall pooled estimates for mean birth weight reported in the synthesis varied across different sampling periods and overall study confidence levels, EPA examined stratum-specific pooled estimates for PFHxS.

### C.1.5 Meta-Analysis Methods

#### Study Inclusion

Thirty-eight developmental epidemiological publications of PFHxS that were identified met our aforementioned inclusion criteria for our meta-analysis (Ru et al., 2024). Some birth cohorts reported BWT analyses for different subsets of their populations in different publications. To avoid double-counting of overlapping study populations, we restricted the meta-analysis to the largest study population sample where multiple publications existed. Specifically, the Woods et al. (2017) study overlapped with the Shoaff et al. (2018) study from the Health Outcomes and Measures of the Environment cohort, and the Bjerregaard-Olesen et al. (2019) study overlapped with Bach et al. (2016a) from the Aarhus Birth Cohort. Following exclusion of Bjerregaard-Olesen et al. (2019) and Woods et al. (2017), there were 36 non-overlapping studies with developmental endpoints of mean BWT changes in relation to PFHxS exposure which advanced to study evaluation. As shown in Figure C-1, five studies (Monroy et al., 2008; Maekawa et al., 2017; Lee and Viberg, 2013; Alkhalawi et al., 2016) were classified as uninformative largely due to critical study deficiencies in at least one risk of bias domain (e.g., confounding and participant selection) or multiple domain deficiencies. Among the remaining 31 studies, study confidence ratings included 7 low confidence studies (Xu et al., 2019; Workman et al., 2019; Shi et al., 2017; Marks et al., 2019b; Gao et al., 2018; Cao et al., 2018; Callan et al., 2016) , 11 medium confidence studies (Meng et al., 2018; Maisonet et al., 2012; Li et al., 2017a; Lenters et al., 2016; Kwon et al., 2016; Kashino et al., 2020; Hjermitslev et al., 2020;Hamm et al., 2010; Gyllenhammar et al., 2018a; Chen et al., 2020a; Chang et al., 2022), and 13 high confidence studies (Yao et al., 2021; Wikström et al., 2020; Valvi et al., 2017; Starling et al., 2017; Shoaff et al., 2018; Sagiv et al., 2018; Manzano-Salgado et al., 2017; Lind et al., 2017; Eick et al., 2020; Buck et al., 2018; Bach et al., 2016b; Ashley-Martin et al., 2017).

Of the 31 informative epidemiological studies with mean BWT data, three studies (Gao et al., 2019; Eick et al., 2020; Cao et al., 2018) reported categorical results only. Our primary analysis was restricted to BWT studies that were most comparable, i.e., those based on continuous PFHxS exposures. Among the 28 studies with results based on continuous data, 24 provided effect estimates in the overall population (i.e., male and female combined). Data were pooled for the four studies that only reported sex-specific findings (Marks et al., 2019b; Maisonet et al., 2012; Lind et al., 2017; Ashley-Martin et al., 2017) within each study using inverse-variance weighting to provide an effect estimate in each study’s overall population. This included male and female-specific results in studies by (Lind et al., 2017) and (Ashley-Martin et al., 2017). The study by Maisonet et al. (2012) and (Marks et al., 2019b) reported sex-specific estimates for girls and boys in different publications from the same Avon Longitudinal Study of Parents and Children (ALSPAC) study population. These two studies were also pooled to obtain an effect estimate in the overall population and included in the meta-analysis labeled henceforth, herein, as (Maisonet et al., 2012). Including these mean birthweight estimates pooled across sexes from these three birth cohorts (Maisonet et al., 2012; Lind et al., 2017; Ashley-Martin et al., 2017) resulted in the inclusion of 27 nonoverlapping informative PFHxS studies (from 28 publications) with continuous exposure expressions for the meta-analysis.

Figure C-1 Twenty-seven informative nonoverlapping perinatal studies of birth weight measures and continuous PFHxS exposure results included in meta-analysis

#### Data Preprocessing

EPA converted the exposure-response functions quantifying the results for the 27 available studies (based on data from 28 publications) using different units into two common exposure metrics of natural (i.e., per ng/mL) or natural log units (i.e., per ln(ng/mL)). For example, to standardize the units and reduce between-study heterogeneity due to the choice of unit, different units such as log_2_, log_10_, and per SD- or IQR-unit changes were converted into a common logarithmic function (natural log) as described below. Four of the 27 included studies were based on natural scale PFHxS data (Shoaff, 2018; Sagiv et al., 2018; Maisonet et al., 2012; Bach et al., 2016a), and EPA used those results to estimate what the results would have been had they been based on a one natural log (ln) unit transformation. This approach was developed by Dzierlenga et al. (2020) and involved plotting the reported linear function for the main effect using 25th–75th percentiles at 10 percentile intervals of the exposure distribution in each study and then fitting a natural logarithmic function to those points. This process was repeated using the reported upper and lower CIs to estimate the bounds of the natural log function and thus the estimated standard error of the natural log function (i.e., standard error = (upper confidence limit – lower confidence limit) / 3.92 (Higgins et al., 2022)).

The meta-analysis was carried out on the natural log scale because the majority (23 out of 27) of the studies reported results on the log scale. Transformations to the log-normal scale are typically employed in epidemiological studies to satisfy regression assumptions. However, the re-scaling methods used by Dzierlenga et al. (2020) and Steenland et al. (2018a) can also be used to express ln-transformed data on the natural scale, which may have useful implications for dose response. A sensitivity analysis was conducted to test the robustness of our analysis to selection of natural or natural log scale (see Sensitivity Analysis Section below).

#### Statistical Analysis

The meta-analysis of the 27 developmental PFHxS studies (from 28 publications) reporting mean birth weight differences was carried out using a random effects model, which follows the assumption that each study produced an estimate of a study-specific true effect that varies across studies (Borenstein et al., 2009). Inverse-variance weighting was employed to minimize the influence of both sampling variance and between-study variance on the pooled effect estimate. The amount of variation due to study heterogeneity was captured by two metrics: the I^2^ statistic and Cochran’s Q test. The I^2^ statistic represents the percent of variation in the pooled estimate due to between-study heterogeneity. The range of values shown in the Cochran’s I^2^ guidelines (Higgins et al., 2022) informed EPA’s consideration of I^2^ statistics <40% to represent “low” potential heterogeneity, with values from 40%–69% being “moderate,” and values ≥70% to represent “high” heterogeneity. Cochran’s Q test evaluates whether the dispersion of study-specific estimates about the pooled effect estimate is statistically significant via a p-value (p_Q_), based on significance level (α) of 0.05. Both metrics may suffer from low statistical power when few studies are available, potentially complicating interpretation of the examinations of heterogeneity. Thus, consideration of both measures in conjunction is recommended to identify situations for which heterogeneity may be present (Huedo-Medina et al., 2006). While the number of studies for the overall analysis may be large enough (n = 27) to not be subject to these concerns, some uncertainty exists for the stratified analyses with considerably fewer studies per strata.

EPA conducted stratified analyses to evaluate whether the summary effect estimate varied by the study confidence rating or by the timing of maternal serum sampling. As detailed in Section 3.2.3, study confidence designations included four low confidence studies (Xu et al., 2019; Workman et al., 2019; Shi et al., 2017; Callan et al., 2016), 11 medium confidence studies (Meng et al., 2018; Maisonet et al., 2012; Li et al., 2017c; Lenters et al., 2016; Kwon et al., 2016; Kashino et al., 2020; Hjermitslev et al., 2020; Hamm et al., 2010; Gyllenhammar et al., 2018b; Chen et al., 2021; Chang et al., 2022), and twelve high confidence studies (Yao et al., 2021; Wikström et al., 2020; Valvi et al., 2017; Starling et al., 2017; Shoaff et al., 2018; Sagiv et al., 2018; Manzano-Salgado et al., 2017; Luo et al., 2021; Lind et al., 2017; Buck Louis et al., 2018; Bach et al., 2016a; Ashley-Martin et al., 2017).

Sample timing strata were defined according to two strategies based on reported gestational age (weeks) at the time of biomarker collection. Strategy 1 was a three-strata approach with subgroups, early (n = 12), late (n = 10) and post (n = 5) pregnancy. Strategy 2 was a two-strata approach, using the same definition of early pregnancy as in Strategy 1, but combining late- and post-pregnancy into a single stratum, late + post (n = 15). Early pregnancy included studies reporting samples from preconception (0 days), the first trimester (0 days to 13 weeks and 6 days) or a mixture of the first and second trimesters (0 days to 27 weeks and 6 days); late pregnancy studies sampled in the second trimester (14 weeks and 0 days to 27 weeks and 6 days), a mixture of the second and third trimester (14 weeks and 0 days to birth), or the third trimester only (28 weeks and 0 days to birth); post-pregnancy studies sampled at or after birth (ACOG, 2020). Studies were assigned to sample timing strata based on reported trimesters of sampling as well as sampling ranges and interquartile ranges or measures of centrality when measures of spread were unavailable (see Table C-3 below for details on sample timing distributions and strata assignments). A sensitivity analysis of the 12 early pregnancy studies was also conducted by comparing the 6 studies (i.e.,(Wikström et al., 2020; Sagiv et al.; Meng et al., 2018; Lind et al., 2017; Harris et al., 2018; Buck Louis et al., 2018; Ashley-Martin et al., 2017) with the earliest sampling (based on predominately first trimester or earlier sampling and/or low measures of centrality of sample timing (e.g., mean, median or mode of gestational age week at sampling ≤10) compared to the remaining 6 early sampled studies that had larger measures of centrality.

The two-strata sample timing approach was also used by previous PFAS meta-analyses (Steenland et al., 2018a; Dzierlenga et al., 2020). However, as noted in (Wright et al., 2023), there may be value in differentiating late maternal samples from post-partum measures and further refining what constitutes early sampling when a sufficient number of studies allow other alternatives. Thus, EPA apportioned studies with late pregnancy samples from those with post-pregnancy samples to better understand differences in sampling matrices, i.e., maternal serum sampled during pregnancy versus umbilical cord samples or postpartum maternal serum samples (i.e., termed post-pregnancy here). Furthermore, the use of more subgroups provides more detail on the gradient of changes that sample timing may be associated with. A sensitivity analysis was employed to assess the robustness of the meta-analysis results to using three strata instead of two.

Strata-specific estimates that allowed for heterogeneity were calculated using a random effects model and a subsequent fixed effects model was used to test for statistically significant differences across the subgroups (Borenstein et al., 2009). A p-value less than 0.05 from this hypothesis test was indicative of no statistically significant differences between any of the strata. Strata-specific statistical tests conducted on subgroups with lower sample sizes are subject to lower power, susceptible to higher uncertainty and therefore should be interpreted with caution. For full details on the computations involved in both the stratified and overall meta-analyses, please refer to the R code developed by EPA (Larsen, 2022).

All statistical analyses are carried out using the open-source platform, R (Version 4.0.3), and all meta-analytic techniques are carried out using the metafor package in R (Viechtbauer, 2010).

Table C-3 Details on study sample timings and strata assignments

Study | Sampling distribution - estimates and measures of centrality (and spread) in gestational weeks | Time period | Sample timing start^a^ | Notes
Ashley-Martin et al. (2017) | N/R (N/R) | Trimester 1 | Early | Sampling time of 9.9 wk was estimated from the trimester 1 midpoint with a range of 6 wk to 13 wk and 6 d.
Bach et al. (2016a) | 12 (9, 20); Mode (Min, Max) | Trimesters 1 and 2 | Early
Buck Louis et al. (2018) | 10, 13.9; (Min, Max) | Trimester 1 | Early | Value of 11.9 wk was estimated as midpoint of the range (10 to 13.9 wk).
Chang et al. (2022) | 11.4 (9.6, 12.6); Median (25%, 75%) | Trimesters 1, 2 | Early
Chen et al. (2021) | 16.3 (13.85, 20.43); Median (Min, Max) | Trimesters 1 and 2 | Early | The authors provided additional data, which showed their serial measures included overlapping trimesters, e.g., their trimester 1 results encompassed trimesters 1 and 2 samples (see Zhang (2022)).
Hjermitslev et al. (2020) | 15.39 (7, 40); (Min, Max) | Trimesters 1, 2, and 3 | Early | This study was assigned to the early strata because sampling predominantly occurred earlier in pregnancy: study authors report that the mean gestational week of sampling in 2010–2011 was week 26.2, and in 2013–2015 all samples were collected before the end of week 13. 38% of samples were taken in 2010–2011; 62% was collected in 2013–2015 (Bonefeld-Jørgensen, 2022).
Lind et al. (2017) | 10 (5, 12); Median (Min, Max) | Trimester 1 | Early
Maisonet et al. (2012); Marks et al. (2019a)^a^ | 10, 228 (25%, 75%); 12, 33 (25%, 75%) | Trimester 1, 2, and 3 | Early
Manzano-Salgado et al. (2017) | 12.3 (5.6); Mean (SD) | Trimester 1, 2, and 3 | Early | Sampling is reported to be all in the first trimester (Manzano-Salgado et al., 2017) supporting information clarifies that some sampling outside of the 1st trimester also occurred (Manzano-Salgado, 2022). However, first trimester sampling was predominant, so this study is designated as conducting “early” sample timing.
Meng et al. (2018) | 8 (4, 14); Mean | Trimesters 1 and 2 | Early | The mean is reported in related publication by Liew et al. (2020).
Sagiv et al. (2018) | 9 (5, 19); Median (Min, Max) | Trimesters 1 and 2 | Early
Wikström et al. (2020) | 10; Median | Trimesters 1 and 2 | Early
Callan et al. (2016) | 37.7 (33, 40); (Min, Max) | Trimester 3 | Late | Samples were taken 2 wk before due date, which ranged from 35 to 42 wk; estimate measure of centrality used here of 37.7 wk.
Hamm et al. (2010) | 15.5 (15, 16); (Min, Max) | Trimester 2 | Late | Measure of centrality of 15.5 wk estimated from the midpoint of the reported range.
Kashino et al. (2020) | 29; Median | Trimester 3 | Late
Lenters et al. (2016) | 25.2; Weighted mean of medians | Trimesters 2 and 3 | Late | Study authors reported country-specific medians: 33 wk (Poland, 18%), 25 weeks (Greenland, 32%), 23 wk (Ukraine, 49%).
Luo et al. (2021) | 39.3; Mean | Trimester 3 | Late
Shoaff et al. (2018) | 18.1; Weighted average | Trimesters 2 and 3, and at delivery | Late | Study was assigned to the late strata instead of post because only 5% of samples taken at delivery, and sensitivity analysis conducted by study authors found results robust to Trimester 2 only. The weighted average was derived the following data provided in the manuscript: “16-week serum samples if available (86%), the 26-wk sample if the 16-wk sample was not available (9%), and if neither of those was available, then the samples from delivery were used (5%).”
Starling et al. (2017) | 27 (20, 34); Median (Min, Max) | Trimesters 2 and 3 | Late
Valvi et al. (2017) | 34; Exact | Trimester 3 | Late
Workman et al. (2019) | 28.6 (14.3, 39.6); Median (Min, Max) | Trimesters 2, 3 | Late | Data provided by authors: Mean = 27.7 wk. Median = 28.6 wk; Range = 14.3–39.6 wk.
Yao et al. (2021) | 39.4; Mean | Trimester 3 | Late
Gyllenhammar et al. (2018b) | 43 (37.9, 46.1); Mean (Range) | Post-Birth | Post | Samples were taken 3 wk after delivery; mean (range) delivery date = 40 wk (34.9, 43.1).
Kwon et al. (2016) | 40; Exact | At Delivery | Post
Li et al. (2017c) | 39; Mean | At Delivery | Post
Shi et al. (2017) | 39.8 (4.2); Mean (SD) | At Delivery | Post
Xu et al. (2019) | 39.4 (1.4); Mean (SD) | At delivery | Post

Abbreviations: N/R: not reported; 25th, 75th%; 25th percentile, 75th percentile of exposure distribution; SD: standard deviation

a Maisonet et al. (2012) was rated as Medium confidence, while Marks et al. (2019b) was Low. This combined population was evaluated as Medium for stratified analyses.

### C.1.6 Meta-Analysis Results

As shown in Figure C-2, the overall pooled birth weight effect estimate for the 27 studies based on the random effects model was −7.9 g ( 95% CI: −15.0, −0.7) per ln ng/mL increase in PFHxS exposure. The tests for heterogeneity showed that between-study variability was negligible (I^2^ = 0%, p_Q_ = 0.85). The meta-analysis results stratified by study confidence are displayed in Table C-4. The 12 high confidence studies yielded a smaller pooled effect estimate of decreased birthweight (β = −6.8 g; 95% CI: −16.3, 2.8) than the 11 medium (β = −10.0 g; 95% CI: −21.1, 1.1) confidence studies; however, the differences between strata were not statistically significant (p = 0.82). There was negligible between-study heterogeneity for the high (I^2^ = 0%, p_Q_ = 0.94) and medium confidence studies, while the low confidence subgroup exhibited “low” heterogeneity (I^2^ = 20.1%, p_Q_ = 0.30). Given the small sample size of the strata (n = 4) and larger and more divergent results, the low confidence combined estimate and heterogeneity statistics are subject to relatively more uncertainty and should be interpreted with caution.

Figure C-2 Forest plot of 27 studies included in the meta-analysis on PFHxS exposures and changes in birth weight

Table C-4 Meta-analysis of PFHxS on birth weight changes (in g per ln(ng/mL)) stratified by study confidence

Set of studies | n | β | 95% confidence interval | I^2^ (%) | p_Q_
All Studies | 27 | −7.9 | −15.0, −0.7 | 0.00 | 0.85
High Confidence | 12 | −6.8 | −16.3, 2.8 | 0.00 | 0.94
Medium Confidence | 11 | −10.0 | −21.1, 1.1 | 0.00 | 0.46
Low Confidence | 4 | −1.5 | −51.6, 48.7 | 20.1 | 0.30
High + Medium Confidence | 23 | −8.1 | −15.4, −0.9 | 0.00 | 0.87

Symbols and abbreviations: n = sample size; β = combined estimate of change in birth weight (g) per ln (ng/mL) PFHxS exposure; I^2^ = % variation in the pooled effect due to study heterogeneity; p_Q_ = p-value for Cochran’s Q test for heterogeneity.

The meta-analysis results stratified by sample timing are displayed in Table C-5. While there are no statistically significant differences between timing subgroups in either the two-strata or the three-strata approach (p = 0.91 and p = 0.30, respectively), there is some evidence that estimated birth weight deficits are greater in later sampling. For example, a fourfold difference in the three-strata approach was seen between the 12 early (β = −7.6 g; 95% CI: −16.2, 1.1) studies and 5 studies based on post-pregnancy samples (β = −28.3 g; 95% CI: −69.3, 12.7). Differences between early and later sampling are slightly more pronounced in the three-strata approach than in the two-strata approach for which the pooled estimate for the late and post-pregnancy samples combined was −8.5 g ( 95% CI: −21.0, 4.1). The estimate for the late pregnancy strata based on 10 studies was null (β = −3.9 g; 95% CI: −17.7, 9.9) but was more comparable in magnitude to the early sampled strata data (β = −7.6 g per each PFHxS ln-unit increase) versus the post-partum studies.

Except for the post-pregnancy strata, heterogeneity observed in each subgroup was negligible for all strata expect the post-pregnancy stratum which had an estimated “low” percent of variation due to heterogeneity, and non-significant Cochran’s Q test (I^2^ = 20.1%, p_Q_ = 0.30). However, the post-pregnancy strata have a sample size of less than ten studies, so results from these heterogeneity tests are expected to be more uncertain.

Table C-5 Meta-analysis of PFHxS on birth weight (in g per ln(ng/mL)) stratified by sample timing

Set of studies | n | β | 95% Confidence interval | I^2^ (%) | p_Q_
All Studies | 27 | −7.9 | −15.0, −0.7 | 0.00 | 0.85
Early Pregnancy | 12 | −7.6 | −16.2, 1.1 | 0.00 | 0.92
Mid- to Late-Pregnancy | 10 | −3.9 | −17.7, 9.9 | 0.00 | 0.85
Post-Pregnancy | 5 | −28.3 | −69.3, 12.7 | 39.8 | 0.19
Mid- to Late- + Post-Pregnancy | 15 | −8.5 | −21.0, 4.1 | 0.00 | 0.49
Early Sample Study Strata
Exclusive T1 or smaller measures of centrality | 6 | −3.5 | −14.8, 7.9 | 0.00 | 0.84
Larger measures of centrality | 6 | −13.4 | −26.9, 0.1 | 0.00 | 0.86

Symbols and abbreviations: n = sample size; β = combined estimate of change in birth weight in g per ln(ng/mL) PFHxS exposure; I^2 =^ % variation in the pooled effect due to study heterogeneity; p_Q =_ p-value for the Cochran’s Q test for heterogeneity.

### C.1.7 Sensitivity Analysis Results

The sensitivity of the meta-analysis results to re-expression was tested by comparing results based on effect estimates re-expressed to the natural log scale to those converted to the natural scale. Table C-6 illustrates that the pooled effect estimates of mean birth weight deficits in our primary analysis are smaller and closer to the null when based on the natural scale but that the patterns in magnitude seen across study confidence and sample timing strata are relatively comparable.

Table C-6 Sensitivity of natural log scale or natural scale re-expression for the overall and stratified meta-analyses of birth weight (in g per ln(ng/mL)

Set of studies | n | β (95% CI) | β (95% CI)
Immune | 27 | −7.9 (−15.0, −0.7) | −2.9 (−6.5, 0.6)
Study Confidence Strata
High | 12 | −6.8 (−16.3, 2.8) | −1.0 (−5.3, 3.2)
Medium | 11 | −10.0 (−21.1, 1.1) | −6.8 (−13.3, −0.4)
Low | 4 | −1.5 (−51.6, 48.7) | −15.9 (−55.2, 23.4)
High + Medium | 23 | −8.1 (−15.4, −0.9) | −2.8 (−6.4, 0.8)
Sample Timing Strata
Early Pregnancy | 12 | −7.6 (−16.2, 1.1) | −3.2 (−8.1, 1.7)
Mid- to Late-Pregnancy | 10 | −3.9 (−17.7, 9.9) | 0.1 (−5.7, 5.9)
Post-Pregnancy | 5 | −28.3 (−69.3, 12.7) | −12.8 (−23.9, −1.6)
Mid to Late + Post | 15 | −8.5 (−21.0, 4.1) | −3.7 (−10.0, 2.6)

Symbols and abbreviations: n = sample size; β = pooled estimate of change in birth weight (g) per ln (ng/mL) or ng/mL PFHxS exposure; CI = confidence interval; T1 = trimester one.

### C.1.8 Summary of Meta-Analysis of PFHxS Effects on Birth Weight

Similar to the hazard synthesis of all the categorical and continuous birth weight results detailed in Section 3.2.2, the meta-analysis pooled estimate of 27 studies showed a statistically significant decrease in mean birth weight of 7.9 g ( 95% CI: −15.0, −0.7) per natural log-unit increase in maternal serum PFHxS. This overall result was similar when studies were restricted to just the medium confidence studies (β = −10.0 g; 95% CI: −21.1, 1.1), high confidence studies (β = −6.8 g; 95% CI: −16.3, 2.8) or the medium + high confidence studies (β = −8.1 g; 95% CI: −15.4, −0.9). These higher quality studies are anticipated to be the least susceptible to potential biases. In contrast, null results were detected among the four low confidence studies (β = −1.5 g; 95% CI: −51.6, 48.7),

Similarly, although a consistent gradation in birth weight deficits was not seen across sample timing, the early sampled stratum has a pooled estimate similar in magnitude (β = −7.6 g) to the overall and the higher confidence studies. Interestingly, this value was fairly comparable to that seen in the later pregnancy sampled studies (β = −3.9 g) in contrast to large differences seen in the postpartum studies which were predominantly based on umbilical cord samples. A four-fold difference was seen when comparing pooled estimates from the twelve early sample studies (β = −7.6 g; 95% CI: −16.2, 1.1) and the five studies with post-pregnancy samples (β = −28.3 g; 95% CI: −69.3, 12.7); however, the CI for the post-pregnancy samples is wide and completely encompasses the CI for the early samples.

Overall, these data are suggestive of a pattern of later sampling times for PFHxS showing larger deficits in birth weight, a pattern that suggests greater bias in later sampled studies. And, although the postpartum sampled studies have considerably larger and more imprecise results, the small decrease of −7.6 grams (per each ln-unit PFHxS increase) from early pregnancy sample studies was not too dissimilar to what was seen amongst studies with other maternal biomarkers sampled such as mid- to late-pregnancy. In comparison to meta-analyses of PFOA (Steenland et al., 2018a) and PFOS (Dzierlenga et al., 2020), a strength of our meta-analysis was the ability to separate results across three different strata since the two-stratum results would not have shown an important contrast. For example, the results for early sampling were similar in magnitude to the remaining studies of mid-/late-pregnancy and post-partum (range: −7.6 to −8.5 g). Further investigation should be undertaken to identify if the large differences between late pregnancy and postpartum samples are unique to PFHxS or is common among PFAS. One interesting finding related to this topic is that recent study reported no decrease in PFHxS serum concentration in serial sampling during pregnancy (Chen et al., 2021), while another study (Taibl et al., 2023), limited by disparate sample sizes across trimester sampling, reported increases in PFHxS levels across pregnancy These findings are in contrast to the other long-chain PFAS which uniformly decreased during pregnancy in the same study, which suggests that maternal physiological changes during pregnancy affect PFHxS differently than other long-chain PFAS.

There was a suggestion of an effect in the overall estimate of all 27 studies as well as the medium and high confidence study and the early sample subsets. The later sampled study strata may still be impacted by potential bias from pregnancy hemodynamics, since the categorization approach was based on samples that may have included a minority of late trimester participants. While the source of any differences between late pregnancy and postpartum remain unclear, the data do suggest that potential bias from pregnancy hemodynamics should continue to be examined as a source of uncertainty in epidemiological studies. The meta-analytical findings along with this research in indicative of complex patterns of influence due to pregnancy hemodynamic differences that are not completely understood. Additional research on the slowly cleared PFAS such as PFHxS is needed to further examine any differences and better delineate the potential impact of pregnancy hemodynamics across the class. The meta-analytical findings along with this research in indicative of complex patterns of influence due to pregnancy hemodynamic differences that are not completely understood.

## C.2 AOP-BASED APPROACH FOR EVALUATING POTENTIAL PFHxS-INDUCED MECHANISMS OF HEPATOTOXICITY MODE OF ACTION

### C.2.1 Objective and Methodology

The goal of the qualitative analysis described here is to evaluate the available mechanistic evidence for PFHxS-induced liver effects to assess the biological plausibility of effects observed in animal models and identify mechanistic pathways that are conserved across species and strains of animals and liver cell culture models and are therefore more relevant to human health. The available mechanistic and toxicological evidence was organized and evaluated in concordance with the frameworks used for mode of action (MOA) analysis for noncancer effects and development of Adverse Outcome Pathways (AOP)^2^ (IPCS, 2007; Edwards et al., 2016; Boobis et al., 2008). PFHxS-induced hepatic effects reported in in vivo and in-cell culture studies were organized according to the following levels of biological organization: molecular interactions, cellular effects, organ effects, and organism effects^3^. As recommended in U.S. EPA (2005), the analysis described here was focused on the concordance of key events and adverse responses across species to obtain clarification on the relevance of animal studies to human health (U.S. EPA, 2005).

In addition to analyzing the available evidence published in the peer-reviewed literature, EPA also considered mechanistic evidence from in vitro high-throughput screening (HTS) assays on PFHxS available from EPA’s CompTox Chemicals Dashboard (https://comptox.epa.gov/dashboard) (U.S. EPA, 2019a). Bioactivity data from the ToxCast and Tox21 collaborative projects were also considered at the same levels of biological organization described below. A more detailed description of the high-throughput (HTS) analysis and results is provided in Appendix C3.

### C.2.2 Proposed AOP Approach for Evaluation of PFAS-Induced Liver Toxicity

The proposed MOA displayed in Figure C-3 is based on molecular initiating events, key events, and adverse outcomes identified in previous mechanistic evaluations and reviews on PFOS and PFOA (U.S. EPA, 2016a, b; Li et al., 2017b; ATSDR, 2021), which are structurally related to PFHxS and among the most well-studied PFAS. Additional reviews on biological pathways associated with chemical-induced cancer and noncancer liver effects were also consulted (see citations below). A summary of the MOA is presented below.

At the molecular level, experimental studies using in vivo and cell culture models have shown that perfluorinated compounds such as PFOS and PFOA can activate several nuclear receptor pathways including the constitutive androstane receptor (CAR), the pregnane X receptor (PXR), the farnesoid X receptor (FXR), the peroxisome proliferator activated receptor alpha (PPARα) and gamma (PPARγ), estrogen receptor alpha (ERα) and other receptor-independent cell signaling pathways (e.g., phosphatidylinositol 3-kinase-serine/threonine protein kinase (PI3KAkt) signal transduction pathway, and the nuclear factor kappa B pathway [NFκB]) (U.S. EPA, 2016a, b; NJDWQI, 2017; Li et al., 2017b; Gleason, 2017; ATSDR, 2021). PFOS- and PFOA induced activation of PPARα is associated with hepatocellular hypertrophy caused by peroxisome proliferation, and increased peroxisomal fatty acid β oxidation and cytochrome P450 4A (CYP4A) expression and activity (U.S. EPA, 2016a, b; ATSDR, 2021), and altered cholesterol metabolism (Li et al., 2017b). Increased PPARα activity can lead to oxidative stress via induction of acyl CoA oxidase expression and activity, and H_2_O_2_ production in peroxisomes (Hall et al., 2012). Several studies have used genetically modified animal and cell culture models and immortalized human cell lines to evaluate potential PFOS or PFOA activation of the human PPARα. COS-1 cells transfected with the murine or human PPARα were responsive to PFAS exposure (U.S. EPA, 2016a, b), and F1 generation PPARα-humanized mice were responsive to PFOA-induced expression responsive genes on GD18, but unlike wild type animals this response was not apparent on PND20 (U.S. EPA, 2016b; Takacs and Abbott, 2007). Studies using human liver cell lines or humanized animal models suggest that humans are less sensitive to PPARα activation by the perfluorinated compounds PFOS and PFOA (reviewed in U.S. EPA (2016a); Li et al. (2017b)). PPARα has also been shown to be activated by exposure to several PFAS, including PFOS, PFOA, PFNA, and PFHxS (Li et al., 2017b; ATSDR, 2021). Although PPARα is not expressed in high levels in the liver, its activation by pharmaceuticals and xenobiotic compounds has been proposed to be associated with hepatic steatosis caused by lipid accumulation (Mellor et al., 2016; Angrish et al., 2016).

As described above exposure to perfluorinated compounds such as PFOS and PFOA has also been shown to activate other nuclear receptor and cell signaling pathways, including the CAR, PXR, FXR, ERα, NFκB, and oxidative stress responsive nuclear factor erythroid 2 related factor 2 (Nrf2) (U.S. EPA, 2016a; Li et al., 2017b; ATSDR, 2021). Furthermore, experiments using null animal models exposed to several PFAS suggest that activation of CAR/PXR occurs independently of PPARα (Li et al., 2017b; ATSDR, 2021). Previous analyses of chemical-induced hepatotoxicity suggest that activation of these cell signaling pathways in experimental models is associated with increased expression and activity of xenobiotic metabolizing enzymes (XMEs) (Joshi-Barve et al., 2015; Hall et al., 2012), formation of reactive metabolites, alterations in cellular lipid metabolism (Angrish et al., 2016), and endoplasmic reticulum damage (Joshi-Barve et al., 2015).

At the cellular level, exposure to PFAS such as PFOS and PFOA has been shown to increase reactive oxygen species production and oxidative damage to cellular macromolecules (U.S. EPA, 2016b; Li et al., 2017b; ATSDR, 2021); promote mitochondrial damage, inhibit mitochondrial function, activate mitochondrial-mediated cell death (U.S. EPA, 2016a; Li et al., 2017b); increase endoplasmic reticulum stress (U.S. EPA, 2016b); induce DNA damage (U.S. EPA, 2016b; ATSDR, 2021); disrupt intercellular gap junction communication (ATSDR, 2021); elevate production/levels of pro-inflammatory cytokines (U.S. EPA, 2016a); alter lipid and glucose metabolism and bile acid biosynthesis (U.S. EPA, 2016a, b); and increase hepatocellular death (U.S. EPA, 2016b; Li et al., 2017b). These pathways/mechanisms are associated with toxicant-induced liver disease and can promote steatohepatitis and fibrosis (Wahlang et al., 2013; Joshi-Barve et al., 2015; Cao et al., 2016; Bessone et al., 2019; Angrish et al., 2016).

Figure C-3 The proposed MOA in the figure above is based on previous analyses on PFAS-induced (e.g., PFOA/PFOS) liver toxicity and the role of nuclear receptor pathways in hepatotoxicity

## C.3 SUMMARY OF RELEVANT HIGH-THROUGHPUT SCREENING ASSAYS FROM EPA’S COMPTOX CHEMICALS DASHBOARD

### C.3.1 In vitro Bioreactivity Data Relevant to the Mechanisms of PFHxS-Induced Liver Effects

In vitro high-throughput screening (HTS) assays for PFHxS were downloaded from EPA’s CompTox Chemicals Dashboard (https://comptox.epa.gov/dashboard) (U.S. EPA, 2019a), which provides bioactivity data from the ToxCast and Tox21 collaborative projects. Available information most pertinent to the analysis of the potential mechanisms of PFHxS-induced liver effects was extracted to supplement and augment mechanistic findings from studies in the peer-reviewed literature previously described. Results (active/inactive, AC50 values, and scaled activity) from in vitro assays were obtained, filtering out background control assays and nonspecific responses from inducible reporter gene assays analyzed in the negative fitting direction relative to the control (‘_dn’)^4^. Bioactivity data were analyzed based on the type of biological response or biological target using the annotation structure within the ToxCast assay summary information (U.S. EPA, 2019a). PFHxS was active in 34 of 743 assays, of which 10 were performed in human liver tissues. PFHxS was active in 0 of 54 unique assay endpoints in human hepatoma HepG2 cells. Most of the active liver relevant endpoint assays were nuclear receptor assays (see Figure C-4, Table C-7).

PFHxS was able to induce reporter assays for multiple nuclear receptors including PPARα, PPARγ, RXR and LXR as well as transcriptional factors, FOS, and NRF2 (see Figure C-5, Table C-7). Nuclear receptor activities were further investigated to provide additional information to known interactions of PFHxS with these receptor-mediated signaling pathways in ToxCast/Tox21 assays profiling multiple endpoints (e.g., receptor binding, co-regulator recruitment and gene transactivation) and cell types (see Figure C-5, Table C-7). As previously mentioned, PFHxS induced activity of specific steroid/xenobiotic sensing receptors, most notably PXR, RXR and PPAR (see Figure C-5). PFHxS interacted with the retinoic acid (RAR, 1 out 19 assays) and the human RXR (1 out of 10) in receptor binding assays. PFHxS was active in 4 out of 27 PPAR-related assays, showing transcriptional activation, including induction of a PPAR-response element driven reporter gene assay, PPAR_α_ and _α_-dependent reporter gene expression and binding to the human PPAR_α_.

Figure C-4 Bioactivity data for PFHxS from in vitro HTS ToxCast/Tox21 assays in human liver tissues

Scatterplots show AC50 and scaled activity values from assays visualized according to the type of biological response or biological target. AC50 values refer to the concentration that elicits half maximal response and the scaled activity refers to the response value divided by the activity cutoff. Assays for which chemicals were inactive are not displayed. Additional information on these assays can be found in Table C-8.

Figure C-5 Summary of positive nuclear receptor assays in human liver tissue

Additional information on these nuclear receptor assays may be found in Table C-7.

Table C-7 Bioactivity summary for PFHxS from in vitro HTS assays from ToxCast/Tox21 conducted in human liver tissue and grouped by biological response/target

Assay name^a,b^ | Activity call | Scaled activity | AC50 (µM) | Assay design
Cell morphology
TOX21_MMP_ratio_up | ACTIVE | 4.19 | 65.1 | Membrane potential reporter
Nuclear receptor
TOX21_RXR_BLA_Agonist_ratio | ACTIVE | 1.31 | 9.28 | Inducible reporter
ATG_ERE_CIS_up | ACTIVE | 2.74 | 96.9 | Inducible reporter
ATG_PPRE_CIS_up | ACTIVE | 1.65 | 44.6 | Inducible reporter
ATG_PPARa_TRANS_up | ACTIVE | 1.35 | 11.2 | Inducible reporter
ATG_PPARg_TRANS_up | ACTIVE | 1.69 | 30.5 | Inducible reporter
NVS_NR_hPPARg | ACTIVE | 1.51 | 27.5 | Binding reporter
ATG_RARg_TRANS_up | ACTIVE | 1.28 | 6.91 | Inducible reporter
ATG_LXRa_TRANS_dn | ACTIVE | 1.53 | 14.4 | Inducible reporter
ATG_PXRE_CIS_up | ACTIVE | 2.77 | 22.0 | Inducible reporter
Transcriptional factor
ATG_AP_1_CIS_up | ACTIVE | 1.25 | 66.5 | Inducible reporter
ATG_NRF2_ARE_CIS_up | ACTIVE | 2.12 | 99.5 | Inducible reporter

a Data were sourced from EPA’s CompTox Chemicals Dashboard (U.S. EPA, 2019a).

b Background control assays, inactive and nonspecific responses from inducible reporter gene assays analyzed in the negative fitting direction relative to the control (‘_dn’) are not presented herein.

NA = not applicable.

### C.3.2 In vitro Bioactivity Data Relevant to the Mechanisms of PFHxS-Induced Thyroid Effects

Table C-8 Endocrine disruptor screening program 21 assay summary results^a^

Assay name | Description | Cell model | Active/inactive
ERE assays
ACEA_ER_80hr | Growth reporter (proliferation) assay | T47D, human breast cell line | Inactive
ATG_ERE_CIS_up | Reporter Gene Assay | HepG2 human hepatoma cell line | Active
ATG_Era_TRANS_up | Reporter Gene Assay | HepG2 human hepatoma cell line | Inactive
NVS_NR_hER | Binding reporter Assay | MCF7, human breast cell line | Inactive
OT_ER_ERaERa_0480 | Binding Reporter Assay | HEK293T, Human Kidney cell line | Inactive
OT_ER_ERaERa_1440 | Binding Reporter Assay | HEK293T, Human Kidney cell line | Inactive
OT_ER_ERbERb_0480 | Binding Reporter Assay | HEK293T, Human Kidney cell line | Inactive
OT_ER_ERbERb_1440 | Binding Reporter Assay | HEK293T, Human Kidney cell line | Inactive
OT_Era_EREGFP_0120 | Reporter Gene Assay | HeLa, Human Cervix cell line | Inactive
OT_Era_EREGFP_0480 | Reporter Gene Assay | HeLa, Human Cervix cell line | Inactive
TOX21_ERa_BLA_Agonist | Reporter Gene Assay | HEK293T, Human Kidney cell line | Inactive
TOX21_ERa_BLA_Antagonist | Reporter Gene Assay | HEK293T, Human Kidney cell line | Inactive
Tox_ERa_LUC_VM7_Agonist | Reporter Gene Assay | VM7, Human Ovary cell line | Inactive
Tox_ERa_LUC_VM7_Antagonist | Reporter Gene Assay | VM7, Human Ovary cell line | Inactive
Tox_ERa_LUC_VM7_Antagonist | Reporter Gene Assay | VM7, Human Ovary cell line | Inactive
Tox_ERb_BLA_Agonist | Binding Reporter Assay | HEK293T, Human Kidney cell line | Inactive
Tox_ERb_BLA_Antagonist | Binding Reporter Assay | HEK293T, Human Kidney cell line | Inactive
OT_ER_ERaERb_0480 | Binding Reporter Assay | HEK293T, Human Kidney cell line | Inactive
OT_ER_ERaERb_1440 | Binding Reporter Assay | HEK293T, Human Kidney cell line | Inactive
TOX21_ERa_BLA_Antagonist_viability | Viability Assay | HEK293T, Human Kidney cell line | Inactive
TOX21_ERa_LUC_VM7_Antagonist_0.5nM_E2_viability | Viability Assay | VM7, Human Ovary cell line | Inactive
ATG_ERa_TRANS_dn | Reporter Gene Assay | HepG2 human hepatoma cell line | Inactive
ATG_ERA_CIS_dn | Reporter Gene Assay | HepG2 human hepatoma cell line | Inactive
ACEA_ER_AUC_viability | Viability Assay | T47D, Human Breast cell line | Inactive
TOX21_ERa_LUC_VM7_Anta gonist_0.1nM_E2_viability | Viability Assay | VM7, Human Ovary cell line | Inactive
TOX21_ERb_BLA_Agonist_viability | Viability Assay | HEK293T, Human Kidney cell line | Inactive
TOX21_ERb_BLA_Antagonist_viability | Viability Assay | HEK293T, Human Kidney cell line | Inactive
AR assays
ATG_AR_TRANS_up | Reporter Gene Assay | HepG2 human hepatoma cell line | Inactive
OT_AR_ARELUC_AG_1440 | Reporter Gene Assay | CHO-K1, Chinese Hamster Ovary | Inactive
OT_AR_ARSRC1_0480 | Binding Assay | HEK293T, Human Kidney cell line | Inactive
OT_AR_ARSRC1_0960 | Binding Assay | HEK293T, Human Kidney cell line | Inactive
TOX21_AR_BLA_Agonist_ | Reporter Gene Assay | HEK293T, Human Kidney cell line | Inactive
TOX21_AR_LUC_Antagonist_ | Reporter Gene Assay | HEK293T, Human Kidney cell line | Inactive
TOX21_AR_LUC_MDAKB2_Agonist | Reporter Gene Assay | MDA-kb2, Human Breast cell line | Inactive
TOX21_AR_LUC_MDAKB2_Antagonist | Reporter Gene Assay | MDA-kb2, Human Breast cell line | Inactive
TOX21_AR_LUC_MDAKB2_Antagonist | Reporter Gene Assay | MDA-kb2, Human Breast cell line | Inactive
TOX21_AR_LUC_MDAKB2_Agonist | Reporter Gene Assay | MDA-kb2, Human Breast cell line | Inactive
ACEA_AR_agonist_80hr | Signaling Assay | 22Rv1, Human Prostate cell line | Inactive
TOX21_AR_BLA_Agonist | Viability Assay | HEK293T, Human Kidney cell line | Inactive
TOX21_AR_LUC_MDAKB2 | Viability Assay | MDA-kb2, Human Breast cell line | Inactive
ATG_AR_TRANS_up | Reporter Gene Assay | HepG2 human hepatoma cell line | Inactive
TOX21_AR_LUC_MDAKB2 | Viability Assay | MDA-kb2, Human Breast cell line | Inactive
TOX21_AR_LUC_MDAKB2 | Viability Assay | MDA-kb2, Human Breast cell line | Inactive
Thyroid Assays
ATG_THRa1_TRANS_up | Reporter Gene Assay | Mammalian cell line (no other information available) | Inactive
NVS_NR_hTRa_Antagonist | Binding Assay | HepG2 human hepatoma cell line | Inactive
TOX21_TSHR_Agonist_ratio | Signaling Assay | Human cell line (no other information available) | Inactive
TOX21_TSHR_Antagonist_ratio | Signaling Assay | HEK293T, Human Kidney cell line | Inactive
TOX21_TR_LUC_GH3_Agonist | Reporter Gene Assay | HEK293T, Human Kidney cell line | Inactive
TOX21_TR_LUC_GH3_Antagonist | Reporter Gene Assay | GH3, Rat pituitary cell line | Inactive
TOX21_TR_LUC_GH3_Antagonist_viability | Viability Assay | GH3, Rat pituitary cell line | Inactive
ATG_THRa1_TRANS_dn | Reporter Gene Assay | HepG2 human hepatoma cell line | Inactive
TOX21_TSHR_wt_ratio | Background Control Assay | HEK293T, Human Kidney cell line | Inactive
NIS_RAIU_inhibition | Binding Assay | HEK293T, Human Kidney cell line | Active
NIS_HEK293T_CTG_Cytotoxicity | Viability Assay | HEK293T, Human Kidney cell line | Inactive
Steroid Assays
NVS_ADME_hCYP19A1 | Enzymatic Activity | Human, Cell Free | Inactive
TOX21_Aromatase_Inhibition | Reporter Gene Assay | MCF-7, Human Breast cell line | Inactive
TOX21_Aromatase_Inhibition_viability | Viability Assay | MCF-7, Human Breast cell line | Inactive

a CompTox Chemistry Dashboard accessed 3/5/2020 https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID3037709#invitrodb-bioassays-toxcast-data.

2 Although the World Health Organization (WHO)-International Programme on Chemical Safety (IPCS)-MOA and the Organization for Economic Co-operation and Development (OECD)-AOP frameworks are similar in the identification and analysis of key events following modified Bradford-Hill criteria (Meek et al., 2014), AOPs are chemical agnostic whereas MOA analyses are intended to inform health assessments of individual (or groups of) chemical(s) (Edwards et al., 2016).

3 Mechanistic evidence from individual chemicals was summarized in a supplementary (MS Excel) database to facilitate the qualitative analysis of the outcomes reported in the available studies.

4 Inducible gene reporter assays were not optimized to detect loss of signal (U.S. EPA, 2019a); therefore, responses from assays analyzed in the negative fitting direction relative to the control (‘_dn’) are considered non-specific and are not presented herein.