# APPENDIX B LITERATURE SEARCH STRATEGY AND POPULATIONS, EXPOSURES, COMPARATORS, AND OUTCOMES (PECO) CRITERIA

## B.1 LITERATURE SEARCH AND SCREENING STRATEGY

Table B-1 Summary of detailed search strategies for perfluorohexanesulfonic acid and related salts (PubMed, Web of Science, Toxline, TSCATS, Toxcenter)

Database | Terms | Hits
Initial strategy
PubMed; 7/24/17 | 108427-53-8[rn] OR 355-46-4[rn] OR “1,1,2,2,3,3,4,4,5,5,6,6,6-Tridecafluorohexane-1-sulfonic acid”[tw] OR “1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-1-Hexanesulfonic acid”[tw] OR “1-Hexanesulfonic acid, 1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-”[tw] OR “1-Hexanesulfonic acid, tridecafluoro-”[tw] OR “1-Perfluorohexanesulfonic acid”[tw] OR “Perfluoro-1-hexanesulfonate”[tw] OR “Perfluorohexane sulfonic acid”[tw] OR “Perfluorohexane-1-sulphonic acid”[tw] OR “Perfluorohexanesulfonate”[tw] OR “Perfluorohexanesulfonic acid”[tw] OR “Perfluorohexylsulfonate”[tw] OR “Tridecafluorohexanesulfonic acid”[tw] OR “tridecafluoro-1-Hexanesulfonic acid”[tw] OR “PFHxS”[tw] | 396
PubMed; 04/29/2020 | ((“108427-53-8”[rn] OR “355-46-4”[rn] OR “1,1,2,2,3,3,4,4,5,5,6,6,6-Tridecafluorohexane-1-sulfonic acid”[tw] OR “1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-1-Hexanesulfonic acid”[tw] OR “1-Hexanesulfonic acid, 1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-”[tw] OR “1-Hexanesulfonic acid, tridecafluoro-”[tw] OR “1-Perfluorohexanesulfonic acid”[tw] OR “Perfluoro-1-hexanesulfonate”[tw] OR “Perfluorohexane sulfonic acid”[tw] OR “Perfluorohexane-1-sulphonic acid”[tw] OR “Perfluorohexanesulfonate”[tw] OR “Perfluorohexanesulfonic acid”[tw] OR “Perfluorohexylsulfonate”[tw] OR “Tridecafluorohexanesulfonic acid”[tw] OR “tridecafluoro-1-Hexanesulfonic acid”[tw] OR “PFHxS”[tw]) AND (“2019/05/03”[Date - Publication] : “3000”[Date - Publication]); (“108427-53-8”[rn]) OR “423-50-7”[rn]) OR “1-Hexanesulfonic acid, 1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-, ion(1-)”[tw]) OR “PFHxS ion(1-)”[tw]) OR “PFHxS_ion”[tw]) OR “Perfluorohexanesulfonate”[tw]) OR “Tridecafluorohexane-1-sulfonate”[tw]) OR “perfluorohexyl sulfonate”[tw]) OR “1,1,2,2,3,3,4,4,5,5,6,6,6-Tridecafluoro-1-hexanesulfonyl fluoride”[tw]) OR “1-Hexanesulfonyl fluoride, 1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-”[tw]) OR “1,1,2,2,3,3,4,4,5,5,6,6,6-Tridecafluoro-1-hexanesulfonic acid”[tw]) OR “EC 206-587-1”[tw]) OR “EINECS 206-587-1”[tw]) OR “PFHS”[tw]) OR “Perfluorhexan-1-sulfonsaure”[tw]) OR “Perfluorohexane sulfonic acid (PFHxS)”[tw]) OR “Perfluorohexane-1-sulphonic acid”[tw]) OR “acide perfluorohexane-1-sulfonique”[tw]) OR “acido perfluorohexano-1-sulfonico”[tw]) OR “perfluorohexane-1-sulphonic acid”[tw]) OR “perfluorohexanesulfonic acid”[tw]) OR “Ammonium Perfluorohexanesulfonate”[tw]) OR “Ammonium perfluorohexanesulfonate”[tw]) OR “PFHxS-H3N”[tw]) OR “PFHxS-K”[tw]) OR “Potassium Perfluorohexanesulfonate”[tw]) OR “Potassium perfluorohexanesulfonate”[tw]) OR “Lithium Perfluorohexanesulfonate”[tw]) OR “Lithium perfluorohexanesulfonate”[tw]) OR “PFHxS-Li”[tw]) AND (“2019/05/03”[Date - Publication] : “3000”[Date - Publication]) | 116
PubMed; 04/06/2021 | ((“108427-53-8”[rn] OR “355-46-4”[rn] OR “1,1,2,2,3,3,4,4,5,5,6,6,6-Tridecafluorohexane-1-sulfonic acid”[tw] OR “1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-1-Hexanesulfonic acid”[tw] OR “1-Hexanesulfonic acid, 1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-”[tw] OR “1-Hexanesulfonic acid, tridecafluoro-”[tw] OR “1-Perfluorohexanesulfonic acid”[tw] OR “Perfluoro-1-hexanesulfonate”[tw] OR “Perfluorohexane sulfonic acid”[tw] OR “Perfluorohexane-1-sulphonic acid”[tw] OR “Perfluorohexanesulfonate”[tw] OR “Perfluorohexanesulfonic acid”[tw] OR “Perfluorohexylsulfonate”[tw] OR “Tridecafluorohexanesulfonic acid”[tw] OR “tridecafluoro-1-Hexanesulfonic acid”[tw] OR “PFHxS”[tw]) AND (“2020/04/29”[Date - Publication] : “3000”[Date - Publication]); (“108427-53-8”[rn] OR “423-50-7”[rn] OR “1-Hexanesulfonic acid, 1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-, ion(1-)”[tw] OR “PFHxS ion(1-)”[tw] OR “PFHxS_ion”[tw] OR “Perfluorohexanesulfonate”[tw] OR “Tridecafluorohexane-1-sulfonate”[tw] OR “perfluorohexyl sulfonate”[tw] OR “1,1,2,2,3,3,4,4,5,5,6,6,6-Tridecafluoro-1-hexanesulfonyl fluoride”[tw] OR “1-Hexanesulfonyl fluoride, 1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro”[tw] OR “1,1,2,2,3,3,4,4,5,5,6,6,6-Tridecafluoro-1-hexanesulfonic acid”[tw] OR “EC 206-587-1”[tw] OR “EINECS 206-587-1”[tw] OR “PFHS”[tw] OR “Perfluorhexan-1-sulfonsaure”[tw] OR “Perfluorohexane sulfonic acid (PFHxS)”[tw] OR “Perfluorohexane-1-sulphonic acid”[tw] OR “acide perfluorohexane-1-sulfonique”[tw] OR “acido perfluorohexano-1-sulfonico”[tw] OR “perfluorohexane-1-sulphonic acid”[tw] OR “perfluorohexanesulfonic acid”[tw] OR “Ammonium Perfluorohexanesulfonate”[tw] OR “Ammonium perfluorohexanesulfonate”[tw] OR “PFHxS-H3N”[tw] OR “PFHxS-K”[tw] OR “Potassium Perfluorohexanesulfonate”[tw] OR “Potassium perfluorohexanesulfonate”[tw] OR “Lithium Perfluorohexanesulfonate”[tw] OR “Lithium perfluorohexanesulfonate”[tw] OR “PFHxS-Li”[tw]) AND (“2020/04/29”[Date - Publication] : “3000”[Date - Publication]) | 28
Web of Science; 7/27/2017 | TS=“1,1,2,2,3,3,4,4,5,5,6,6,6-Tridecafluorohexane-1-sulfonic acid” OR TS=“1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-1-Hexanesulfonic acid” OR TS=“1-Hexanesulfonic acid, 1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-” OR TS=“1-Hexanesulfonic acid, tridecafluoro-” OR TS=“1-Perfluorohexanesulfonic acid” OR TS=“Perfluoro-1-hexanesulfonate” OR TS=“Perfluorohexane sulfonic acid” OR TS=“Perfluorohexane-1-sulphonic acid” OR TS=“Perfluorohexanesulfonate” OR TS=“Perfluorohexanesulfonic acid” OR TS=“Perfluorohexylsulfonate” OR TS=“Tridecafluorohexanesulfonic acid” OR TS=“tridecafluoro-1-Hexanesulfonic acid” OR TS=“PFHxS” | 394
Web of Science; 04/29/2020 | ((TS=“1,1,2,2,3,3,4,4,5,5,6,6,6-Tridecafluorohexane-1-sulfonic acid” OR TS=“1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-1-Hexanesulfonic acid” OR TS=“1-Hexanesulfonic acid, 1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-” OR TS=“1-Hexanesulfonic acid, tridecafluoro-” OR TS=“1-Perfluorohexanesulfonic acid” OR TS=“Perfluoro-1-hexanesulfonate” OR TS=“Perfluorohexane sulfonic acid” OR TS=“Perfluorohexane-1-sulphonic acid” OR TS=“Perfluorohexanesulfonate” OR TS=“Perfluorohexanesulfonic acid” OR TS=“Perfluorohexylsulfonate” OR TS=“Tridecafluorohexanesulfonic acid” OR TS=“tridecafluoro-1-Hexanesulfonic acid” OR TS=“PFHxS”) AND PY=2019-2020); ((TS=“1-Hexanesulfonic acid, 1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-, ion(1-)” OR TS=“PFHxS ion(1-)” OR TS=“PFHxS_ion” OR TS=“Perfluorohexanesulfonate” OR TS=“Tridecafluorohexane-1-sulfonate” OR TS=“perfluorohexyl sulfonate” OR TS=“1,1,2,2,3,3,4,4,5,5,6,6,6-Tridecafluoro-1-hexanesulfonyl fluoride” OR TS=“1-Hexanesulfonyl fluoride, 1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-” OR TS=“1,1,2,2,3,3,4,4,5,5,6,6,6-Tridecafluoro-1-hexanesulfonic acid” OR TS=“EC 206-587-1” OR TS=“EINECS 206-587-1” OR TS=“PFHS” OR TS=“Perfluorhexan-1-sulfonsaure” OR TS=“Perfluorohexane sulfonic acid (PFHxS)” OR TS=“Perfluorohexane-1-sulphonic acid” OR TS=“acide perfluorohexane-1-sulfonique” OR TS=“acido perfluorohexano-1-sulfonico” OR TS=“perfluorohexane-1-sulphonic acid” OR TS=“perfluorohexanesulfonic acid” OR TS=“Ammonium Perfluorohexanesulfonate” OR TS=“Ammonium perfluorohexanesulfonate” OR TS=“PFHxS-H3N” OR TS=“PFHxS-K” OR TS=“Potassium Perfluorohexanesulfonate” OR TS=“Potassium perfluorohexanesulfonate” OR TS=“Lithium Perfluorohexanesulfonate” OR TS=“Lithium perfluorohexanesulfonate” OR TS=“PFHxS-Li”) AND PY=2019-2020) | 90
Web of Science; 04/06/2021 | ((TS=“1,1,2,2,3,3,4,4,5,5,6,6,6-Tridecafluorohexane-1-sulfonic acid” OR TS=“1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-1-Hexanesulfonic acid” OR TS=“1-Hexanesulfonic acid, 1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-” OR TS=“1-Hexanesulfonic acid, tridecafluoro-” OR TS=“1-Perfluorohexanesulfonic acid” OR TS=“Perfluoro-1-hexanesulfonate” OR TS=“Perfluorohexane sulfonic acid” OR TS=“Perfluorohexane-1-sulphonic acid” OR TS=“Perfluorohexanesulfonate” OR TS=“Perfluorohexanesulfonic acid” OR TS=“Perfluorohexylsulfonate” OR TS=“Tridecafluorohexanesulfonic acid” OR TS=“tridecafluoro-1-Hexanesulfonic acid” OR TS=“PFHxS”) AND PY=2020-2021); ((TS=“1-Hexanesulfonic acid, 1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-, ion(1-)” OR TS=“PFHxS ion(1-)” OR TS=“PFHxS_ion” OR TS=“Perfluorohexanesulfonate” OR TS=“Tridecafluorohexane-1-sulfonate” OR TS=“perfluorohexyl sulfonate” OR TS=“1,1,2,2,3,3,4,4,5,5,6,6,6-Tridecafluoro-1-hexanesulfonyl fluoride” OR TS=“1-Hexanesulfonyl fluoride, 1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-” OR TS=“1,1,2,2,3,3,4,4,5,5,6,6,6-Tridecafluoro-1-hexanesulfonic acid” OR TS=“EC 206-587-1” OR TS=“EINECS 206-587-1” OR TS=“PFHS” OR TS=“Perfluorhexan-1-sulfonsaure” OR TS=“Perfluorohexane sulfonic acid (PFHxS)” OR TS=“Perfluorohexane-1-sulphonic acid” OR TS=“acide perfluorohexane-1-sulfonique” OR TS=“acido perfluorohexano-1-sulfonico” OR TS=“perfluorohexane-1-sulphonic acid” OR TS=“perfluorohexanesulfonic acid” OR TS=“Ammonium Perfluorohexanesulfonate” OR TS=“Ammonium perfluorohexanesulfonate” OR TS=“PFHxS-H3N” OR TS=“PFHxS-K” OR TS=“Potassium Perfluorohexanesulfonate” OR TS=“Potassium perfluorohexanesulfonate” OR TS=“Lithium Perfluorohexanesulfonate” OR TS=“Lithium perfluorohexanesulfonate” OR TS=“PFHxS-Li”) AND PY=2020-2021) | 69
Toxline; 7/21/2017 | ( 108427-53-8[rn] OR 355-46-4[rn] OR “1,1,2,2,3,3,4,4,5,5,6,6,6-Tridecafluorohexane-1-sulfonic acid” OR “1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-1-Hexanesulfonic acid” OR “1-Hexanesulfonic acid, 1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-” OR “1-Hexanesulfonic acid, tridecafluoro-” OR “1-Perfluorohexanesulfonic acid” OR “Perfluoro-1-hexanesulfonate” OR “Perfluorohexane sulfonic acid” OR “Perfluorohexane-1-sulphonic acid” OR “Perfluorohexanesulfonate” OR “Perfluorohexanesulfonic acid” OR “Perfluorohexylsulfonate” OR “Tridecafluorohexanesulfonic acid” OR “tridecafluoro-1-Hexanesulfonic acid” OR “PFHxS” ) AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) [not] PubMed [org] [not] pubdart [org] | 0
SCOPUS (new search); 4/26/2021 | (“108427-53-8” OR “355-46-4” OR “1,1,2,2,3,3,4,4,5,5,6,6,6-Tridecafluorohexane-1-sulfonic acid” OR “1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-1-Hexanesulfonic acid” OR “1-Hexanesulfonic acid, 1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-” OR “1-Hexanesulfonic acid, tridecafluoro-” OR “1-Perfluorohexanesulfonic acid” OR “Perfluoro-1-hexanesulfonate” OR “Perfluorohexane sulfonic acid” OR “Perfluorohexane-1-sulphonic acid” OR “Perfluorohexanesulfonate” OR “Perfluorohexanesulfonic acid” OR “Perfluorohexylsulfonate” OR “Tridecafluorohexanesulfonic acid” OR “tridecafluoro-1-Hexanesulfonic acid” OR “PFHxS”); (“108427-53-8” OR “423-50-7” OR “1-Hexanesulfonic acid, 1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-, ion(1-)” OR “PFHxS ion(1-)” OR “PFHxS_ion” OR “Perfluorohexanesulfonate” OR “Tridecafluorohexane-1-sulfonate” OR “perfluorohexyl sulfonate” OR “1,1,2,2,3,3,4,4,5,5,6,6,6-Tridecafluoro-1-hexanesulfonyl fluoride” OR “1-Hexanesulfonyl fluoride, 1,1,2,2,3,3,4,4,5,5,6,6,6-tridecafluoro-” OR “1,1,2,2,3,3,4,4,5,5,6,6,6-Tridecafluoro-1-hexanesulfonic acid” OR “EC 206-587-1” OR “EINECS 206-587-1” OR “PFHS” OR “Perfluorhexan-1-sulfonsaure” OR “Perfluorohexane sulfonic acid (PFHxS)” OR “Perfluorohexane-1-sulphonic acid” OR “acide perfluorohexane-1-sulfonique” OR “acido perfluorohexano-1-sulfonico” OR “perfluorohexane-1-sulphonic acid” OR “perfluorohexanesulfonic acid” OR “Ammonium Perfluorohexanesulfonate” OR “Ammonium perfluorohexanesulfonate” OR “PFHxS-H3N” OR “PFHxS-K” OR “Potassium Perfluorohexanesulfonate” OR “Potassium perfluorohexanesulfonate” OR “Lithium Perfluorohexanesulfonate” OR “Lithium perfluorohexanesulfonate” OR “PFHxS-Li”) | 1,208
TSCATS2, TSCA recent notices; 7/21/2017 | 84-66-2 | 10
TSCATS2, TSCA recent notices; 7/21/2017 | 84-66-2 (8E OR FYI) TSCA | 0 recent notice

Table B-2 Processes used to augment the search of core databases for PFHxS (355-46-4)

System used | Selected key reference(s) or sources | References identified
TSCATS^a^ | TSCATS2 (https://yosemite.epa.gov/oppts/epatscat8.nsf/ReportSearch?OpenForm) | 2
TSCATS^a^ | Chemical Data Access Tool (CDAT) (https://java.epa.gov/oppt chemical search/ (https://java.epa.gov/oppt_chemical_search/)) | 1
TSCATS^a^ | ChemView (https://java.epa.gov/chemview) | 1
Resources searched for physiochemical property information | Agency for Toxic Substances and Disease Registry (ATSDR) (https://www.atsdr.cdc.gov/); Australian National Industrial Chemicals Notification and Assessment Scheme (NICNAS) (https://www.nicnas.gov.au/chemical-information); [underlined: CAMEO Chemicals] (https://cameochemicals.noaa.gov/); [underlined: Canada DSL List] (http://webnet.oecd.org/CCRWEB/Search.aspx); [underlined: ChemIDplus] (https://chem.nlm.nih.gov/chemidplus/); [underlined: ChemSpider] (http://www.chemspider.com/); [underlined: Chemical Risk Information Platform (CHRIP)] (http://www.nite.go.jp/en/chem/chrip/chrip search/systemTop (http://www.nite.go.jp/en/chem/chrip/chrip_search/systemTop)); [underlined: CRC Handbook of Chemistry and Physics] (http://hbcponline.com/faces/contents/ContentsSearch.xhtml;jsessionid=9408875156F724E0E945D3A6D0454891); [underlined: ECHA Information on Chemicals] (https://echa.europa.eu/); [underlined: eChemPortal] (https://www.echemportal.org/echemportal/index.action); [underlined: SRC Fate Pointers] (http://esc.syrres.com/fatepointer/search.asp); [underlined: Hazardous Substances Data Bank (HSDB)] https://toxnet.nlm.nih.gov/cgi-bin/sis/htmlgen?HSDB); [underlined: HSNO Chemical Classification and Information Database (CCID)] (http://www.epa.govt.nz/search-databases/Pages/HSNO-CCID.aspx); [underlined: Integrated Risk Information System (IRIS)] (https://www.epa.gov/iris); [underlined: IARC Monographs] (http://www.inchem.org/pages/iarc.html); [underlined: J-Check] (http://www.safe.nite.go.jp/jcheck/search.action?requestlocale=en (http://www.safe.nite.go.jp/jcheck/search.action?request_locale=en)); [underlined: Kirk-Othmer Encyclopedia of Chemical Technology] (http://onlinelibrary.wiley.com/mrw/advanced/search?doi=10.1002/0471238961); [underlined: NIEHS] (https://www.niehs.nih.gov/); [underlined: OSHA Occupational Chemical Database] (https://www.osha.gov/chemicaldata/); [underlined: PubChem] (https://pubchem.ncbi.nlm.nih.gov/search/index.html); [underlined: Ullmann’s Encyclopedia] http://onlinelibrary.wiley.com/mrw/advanced/search?doi=10.1002/14356007); [underlined: USEPA ACToR] (https://actor.epa.gov/actor/home.xhtml); [underlined: USEPA ChemView] (https://java.epa.gov/chemview); [underlined: USEPA Substance Registry Services (SRS)] (https://ofmpub.epa.gov/sorinternet/registry/substreg/searchandretrieve/substancesearch/search.do (https://ofmpub.epa.gov/sor_internet/registry/substreg/searchandretrieve/substancesearch/search.do)); [underlined: USEPA CDAT] (https://java.epa.gov/opptchemicalsearch/); [underlined: USEPA Chemistry Dashboard] (https://comptox.epa.gov/dashboard/); Web based search for chemical manufacturer documents | 5
Resources searched for health effects, toxicokinetic, and mechanistic information | ATSDR (http://www.atsdr.cdc.gov/substances/index.asp); CalEPA OEHHA (http://www.oehha.ca.gov/risk.html); OEHHA Toxicity Criteria Database (http://www.oehha.ca.gov/tcdb/index.asp); CPSC (http://www.cpsc.gov); ECHA (http://echa.europa.eu/information-on-chemicals); European Union Risk Assessment Reports (https://ec.europa.eu/jrc/en/publications-list); EFSA Europe (http://www.efsa.europa.eu/); eChemPortal^b^ (http://www.echemportal.org/echemportal/participant/page.action?pageID=9); eChemPortal^b^ (http://www.echemportal.org/echemportal/participant/page.action?pageID=9); Environment Canada (http://www.ec.gc.ca/default.asp?lang=En&n=ECD35C36); Health Canada (https://www.canada.ca/en/health-canada.html); USEPA NSCEP (https://www.epa.gov/nscep); FDA (http://www.fda.gov/); Federal Docket (http://www.regulations.gov); IARC (http://monographs.iarc.fr/ENG/Classification/index.php); ITER (http://www.tera.org/iter/); Japan Existing Chemical Data Base (http://dra4.nihs.go.jp/mhlwdata/jsp/SearchPageENG.jsp (http://dra4.nihs.go.jp/mhlw_data/jsp/SearchPageENG.jsp)); NIEHS (http://www.niehs.nih.gov/); NICNAS (http://www.nicnas.gov.au/chemical-information); NTP (http://ntpsearch.niehs.nih.gov/home); WHO (http://www.who.int/ipcs/assessment/en/) | 2

a Only relevant TSCATS studies from these interfaces were added to the HERO project page.

b eChemPortal includes the following databases: ACToR, AGRITOX, CCR, CCR DATA, CESAR, CHRIP, ECHA CHEM, EnviChem, ESIS, GHS-J, HPVIS, HSDB, HSNO CCID, INCHEM, J-CHECK, JECDB, NICNAS PEC, OECD-HPV, OECD SIDS IUCLID, SIDS UNEP, UK CCRMP Outputs, EPA-IRIS, and EPA-SRS.

## B.2 TITLE AND ABSTRACT LEVEL SCREENING CRITERIA FOR THE INITIAL LITERATURE SEARCHES

Table B-3 Title and abstract level screening criteria for the initial literature searches

| Inclusion criteria | Exclusion criteria
Population | - Humans; - Standard mammalian animal models, including rat, mouse, rabbit, guinea pig, hamster, monkey, dog; - Alternative animal models in standard laboratory conditions (e.g., Xenopus, zebrafish, minipig); - Human or animal cells, tissues, or organs (not whole animals); bacteria, nonmammalian eukaryotes; other nonmammalian laboratory species | - Ecological species
Exposure | - Exposure is to PFHxS compound; - Exposure via oral, inhalation, dermal, intraperitoneal, or intravenous injection routes; - Exposure is measured in air, dust, drinking water, diet, gavage, or injection vehicle or via a biomarker of exposure (PFHxS levels in whole blood, serum, plasma, or breastmilk) | - Study population is not exposed to a PFHxS compound; - Exposure is to a mixture only
Outcome | - Studies that include a measure of one or more health effect endpoints including, but not limited to, effects on reproduction, development, developmental neurotoxicity, liver, thyroid, immune system, nervous system, genotoxicity, and cancer; - In vivo and/or in vitro studies related to toxicity mechanisms, physiological effects/adverse outcomes, and studies useful for elucidating toxic modes of action (MOAs); - Qualitative or quantitative description of absorption, distribution, metabolism, excretion, toxicokinetic and/or toxicodynamic models (e.g., PBPK, PBTK, PBTK/TD); - Studies addressing risks to infants, children, pregnant women, occupational workers, the elderly, and any other susceptible or differentially exposed populations
Other | - Structure and physiochemical properties; - Reviews and regulatory documents | - Not on topic, including:; - Abstract only, inadequately reported abstract, or no abstract and not considered further because study was not potentially relevant; - Bioremediation, biodegradation, or chemical or physical treatment of PFHxS compounds, including evaluation of wastewater treatment technologies and methods for remediation or contaminated water and soil; - Ecosystem effects, studies in ecological species that are not relevant to health effects; - Studies of environmental fate and transport of PFHxS compounds in environmental media; - Analytical methods for detecting/measuring PFHxS compounds in environmental media and use in sample preparations and assays.; - Studies describing the manufacture and use of PFHxS compounds; - Not chemical-specific (studies that do not involve testing of PFHxS compounds); - Studies that describe measures of exposure to PFHxS compounds without data on associated health effects

Table B-4 Example DistillerSR form questions to be used for title/abstract level and full text level screening for literature search updates from 2019

Used in title/abstract and full text screening | | | | | | Used in full text screening only
Question | Source of study if not identified from database search? | Does the article meet PECO criteria? | If meets PECO, what type of evidence? | If supplemental, what type of information? | Which PFAS did the study report? | If meets PECO, which health outcome(s) apply? | If meets PECO and endocrine outcome, which endocrine tags apply?
Answer options (can select multiple options) | - Source other than HERO database search | - Yes; - No; - Unclear; - Tag as potentially relevant supplemental information | - Human; - Animal (mammalian models); - In vitro or in silico genotoxicity; - PBPK or PK model | - In vivo mechanistic or MOA studies, including non-PECO routes of exposure (e.g., injection) and populations (e.g., nonmammalian); - In vitro or in silico studies (nongenotoxicity); - ADME/toxicokinetic (excluding models); - Exposure assessment or characterization (no health outcome); - PFAS mixture study (no individual PFAS comparisons); - Human case reports or case series; - Ecotoxicity studies; - Environmental fate or occurrence (including food); - Manufacture, engineering, use, treatment, remediation, or laboratory methods; - Other assessments or records with no original data (e.g., reviews, editorials, commentaries) | - PFBA; - PFHxA; - PFHxS; - PFNA; - PFDA | - General toxicity, including body weight, mortality, and survival; - Cancer; - Cardiovascular, including serum lipids; - Endocrine (hormone); - Gastrointestinal; - Genotoxicity; - Growth (early life) and development; - Hematological, including nonimmune/ hepatic/ renal clinical chemistry measures; - Hepatic, including liver measures and serum markers (e.g., ALT; AST); - Immune/inflammation; - Musculoskeletal; - Nervous system, including behavior and sensory function; - Nutrition and metabolic; - Ocular; - PBPK or PK model; - Renal, including urinary measures (e.g., protein); - Reproductive; - Respiratory; - Skin and connective tissue effects | - Adrenal; - Sex hormones (e.g., androgen; estrogen; progesterone); - Neuroendocrine; - Pituitary; - Steroidogenesi; - Thyroid

## B.3 DOCUMENTATION OF LITERATURE SEARCH UPDATES AFTER APRIL 2022

Table B-5 documents the decisions regarding studies identified after April 2022, including a literature search update in April 2023 and studies identified in public comments received through the EPA docket on the draft IRIS PFDA assessment^1^ and the draft IRIS PFHxS assessment. The table focuses primarily on the new studies that met the assessment PECO criteria. Table B-5 provides EPA’s disposition on the decision to incorporate these studies into the assessment as defined in draft Peer Review Charge question 1 (i.e., only incorporating studies that may potentially change which hazards are identified, or notably affect the RfDs, or studies that directly inform the identified key science issues); the charge question asks the peer reviewers to weigh in on EPA’s disposition. These same criteria were applied to certain categories of newly identified supplemental studies (i.e., ADME and mechanistic studies, including non-PECO exposure route studies). Thus, in addition to providing this characterization for all studies that meet PECO criteria, Table B-5 also includes studies from supplemental evidence categories that were determined to warrant inclusion in the assessment based on the criteria described above. The decision to exclude other recently identified studies that meet these specific supplemental evidence categories is documented in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500074/PFHxS-New-Studies-2023/). Recently identified studies that meet supplemental evidence categories other than those above (e.g., exposure-only) were not evaluated in this way and are tagged in HERO (https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/2630) and HAWC (https://hawc.epa.gov/summary/visual/assessment/100500074/PFHxS-New-Studies-2023/) along with other screening decisions (e.g., excluded studies).

Table B-5 Summary of decisions regarding studies identified after April 2022, including characterization of all studies meeting PECO criteria and all supplemental studies added to the assessment syntheses

Reference | Source | Health outcome | Results summary | EPA disposition on incorporation and characterization of impact
Immune effects in humans
Kaur et al. (2023) | Lit update | Antibody levels to SARS-COV2 in adults | Inverse association (beta −0.68; 95% CI: −1.18, −0.18) | No.; Findings are consistent with existing evidence and have no impact on immunosuppression conclusions, particularly given that two of the new studies are in adults and the draft conclusions are primarily based on studies in children.
Porter et al. (2022) | Lit update | Antibody levels to SARS-COV2 in adults | Inverse association with IgG and neutralizing antibodies in response to COVID vaccination (statistical significance varied based on model)
Zhang et al. (2023b) | Lit update | Vaccine response | Inverse association with rubella antibodies (−6.48% change; 95% CI: −10.69, −2.07). Inverse but not statistically significant association with mumps antibodies in sub-population with lower folate
Mogensen et al. (2015) | Commenter | Vaccine response | Re-analysis of Faroe Islands study, showing results when analyzed with structural equation modeling | Multipollutant modeling results will be added to discussion of potential confounding across PFAS.
Zhang et al. (2022) | Lit update | Infectious disease | Positive association with common cold at 3– 11 years (OR = 1.31; 95% CI: 1.05, 1.63) but not 12–19 years | No.; Existing evidence on infectious disease is inconsistent and new studies do not change current draft judgment.
Huang et al. (2020) | Commenter | Infectious disease | No association with the number of respiratory tract infections in preschool children | No.; Existing evidence on infectious disease is inconsistent and new studies do not change current draft judgment.
Pan et al. (2023) | Lit update | Asthma | No association with current asthma (OR = 0.97; 95% CI: 0.57, 1.65 in Q4 vs. Q1) or wheezing. Inverse association with asthma attacks and emergency visits | No.; Existing evidence on asthma is inconsistent and new studies do not change current draft judgment.
Gaylord et al. (2019) | Commenter (on PFDA) | Asthma | No association with asthma diagnosis (OR = 0.96; 95% CI: 0.65, 1.44) | No.; Existing evidence on asthma is inconsistent and new studies do not change current draft judgment.
Averina et al. (2019) | Commenter (on PFDA) | Asthma | Positive association with asthma (OR = 2.18; 95% CI: 1.08, 4.42 in Q4 vs. Q1). No association with allergies or eczema | No.; Existing evidence on asthma is inconsistent and new studies do not change current draft judgment.
Van Larebeke et al. (2023) | Peer review | Asthma, other hypersensitivity outcomes | Inverse but not statistically significant associations with asthma (current or ever), eczema. Statistically significant inverse association with allergic rhinitis. Positive but not statistically significant association with systemic allergy | No.; Existing evidence on asthma is inconsistent and new studies do not change current draft judgment.
Wen et al. (2019) | Commenter | Atopic dermatitis | Positive but not statistically significant association with atopic dermatitis | No.; Existing evidence on asthma is inconsistent and new studies do not change current draft judgment.
Ammitzbøll et al. (2019) | Commenter (on PFDA) | Multiple sclerosis | No association with multiple sclerosis (2% change; 95% CI: −9,15) | No.; Mixed results for autoimmune conditions in new studies would not influence draft conclusions on immune effects.
Gaylord et al. (2020) | Commenter (on PFDA) | Celiac disease | Positive association with celiac disease (OR=1.72; 95% CI: 0.85, 3.49) with stronger effect in women (OR = 3.24; 95% CI: 1.04, 10.11) | No.; Mixed results for autoimmune conditions in new studies would not influence draft conclusions on immune effects.
Steenland et al. (2018b) | Commenter | Ulcerative colitis | Inverse association with ulcerative colitis | No.; Mixed results for autoimmune conditions in new studies would not influence draft conclusions on immune effects.
Immune effects in animals
Narizzano et al. (2023) | ERG panel member | Immune and reproductive | PFHxS induced decreased functional immunity in deer mice | No, results do not influence draft judgments or provide key insights into key science issues, nor do they provide additional insights into potential mechanisms of PFHxS-induced effects.
Weatherly et al. (2024) | Commenter | Immune | Topical administration of PFHxS increased spleen size and reduced humoral immune response and altered immune subsets in the spleen | No, the study did not meet PECO criteria as outlines in protocol document. Further, results do not influence draft judgments or provide key insights into key science issues, nor do they provide additional insights into potential mechanisms of PFHxS-induced effects.
Developmental effects in humans
Wang et al. (2023a) | Lit update | Fetal growth restriction | No sex-specific associations were observed for birth length (BL), birth weight (BW) and head circumference (HC) endpoints.; BL Male β = −0.080; 95% CI: −0.062, 0.222; BL Female β = −0.004; 95% CI: −0.310, 0.303.; HC Male β = 0.005; 95% CI: −0.180, 0.191; HC Female β = −0.110; 95% CI: −0.345, 0.125.; BW Male β = 0.024; 95% CI: −0.140, 0.188; BW Female β = −0.062; 95% CI: −0.291, 0.166 | No. Findings across the new studies were mixed with some positive, inverse, and null findings across various endpoints. So, these would not change the current human evidence synthesis for fetal growth restriction or the developmental effects judgment (i.e., slight).
Peterson et al. (2022) | Lit update | Fetal growth restriction | No associations were evident across fetal measures in relation to PFHxS exposures
Wang et al. (2023b) | Lit update | Fetal growth restriction | No associations were evident across fetal growth endpoints [per each PFHxS log_10_ increase, BW z-score −0.06 (95% CI: −0.25, 0.12), BL z-score −0.10 (95% CI: −0.36, 0.17), HC z score 0.08 (95% CI: −0.18, 0.35), Ponderal index −0.04 (95% CI: −0.72, 0.64), weight for length z-score 0.02 (95% CI: −0.29, 0.34)]
Ouidir et al. (2020) | Commenter (on PFDA) | Fetal growth restriction | Per each PFHxS IQR increase, a statistically significant longitudinal decrease in HC (β = −0.22 mm; p-value: <0.05) and increases in longitudinal biparietal diameter (β = 0.07 mm; p-value: <0.05), and femur length (β = 0.12 mm; p-value: <0.001) were detected. Results for other endpoints were null. Study population was previously reported in a publication already in the assessment Buck Louis et al. (2018), and new longitudinal in utero results would not change the current draft judgment
Hu et al. (2021) | Commenter | Fetal growth restriction | Null results were seen for BW per each 2-fold PFHxS increase (β = −6.7 g; 95% CI: −11.4, 24.8), but study was duplicative with another publication Ashley-Martin et al. (2017) already included in the assessment
Kalloo et al. (2020) | Commenter | Fetal growth restriction, gestational age | These anthropometric measures of fetal growth and gestational duration from this study population (HOME study) were previously reported in a publication already in the assessment Shoaff et al. (2018). We also previously demonstrated in Appendix C that single PFHxS vs. multi-PFAS models were comparable
Mwapasa et al. (2023) | Lit update | Fetal growth restriction, gestational age | Per each log_10_ PFHxS increase, deficits were seen for BW (β = −189 g; 95% CI: −371, −6) and Ponderal Index (β = −0.090; 95% CI: −0.175, −0.005). In contrast, increased HC was detected (β = 0.048 cm; 95% CI: 0.001, 0.095). Other endpoints, such as BL (β = 0.014 cm; 95% CI: −0.011, 0.038), gestational age (β = −0.160 wk; 95% CI: −0.076, 0.044) were not statistically significant
Siwakoti et al. (2023) | Peer review (PFHxS) | Fetal growth restriction, Preterm birth (PTB) | Null results for fetal growth restriction detected for BW z-score and small for gestational age (SGA) (Table S4a). Association of PTB and PFHxS was also null (OR = 1.04; 95% CI: 0.79, 1.37, Table S3a)
Padula et al. (2023) | Lit update | Fetal growth restriction, PTB gestational age | No associations were evident across fetal growth and gestational duration endpoints [gestational age β = 0.02; 95% CI: −0.19, 0.23; BW for gestational age β = −0.06; 95% CI: −0.18, 0.06; term low BW OR = 1.14; 95% CI: 0.46, 2.84; SGA OR = 1.25; 95% CI: 0.84, 1.87; large for gestational age OR = 0.86; 95% CI: 0.59, 1.25; PTB OR = 0.97; 95% CI: 0.61, 1.55]
Qin et al. (2023b) | Peer review (PFHxS) | Preterm birth | Association of PTB and PFHxS was null (OR = 0.96; 95% CI: 0.77, 1.20 per each ln-unit increase) | No. Findings across the new studies were mixed, which is consistent with existing literature base captured in the synthesis. So, these would not change the current human evidence synthesis for gestational duration or the developmental effects judgment (i.e., slight).
Liao et al. (2022b) | Lit update | Preterm birth | Results were mixed with a statistically significant decrease in PTB per each log_10_ increase (OR = 0.73; 95% CI: 0.39, 1.38) driven by tertile 3 (OR = 0.60; 95% CI: 0.37, 0.98); results were null for tertile 2 (OR = 0.97; 95% CI: 0.63, 1.50)
Yu et al. (2022) | Lit update | Preterm birth | Results were mixed with a non-significant increase in PTB risk seen for untransformed data (OR = 1.76; 95% CI: 0.91, 3.40 per each ng/mL increase) only; transformed results were null (OR = 0.93; 95% CI: 0.80, 1.08 per each ln PFHxS increase)
Petroff et al. (2023) | Lit update | Gestational age | No association between PFHxS exposure and gestational age (β = 0.04 ± 0.21; p = 0.85)
Wang et al. (2016) | Public comment (PFNA) | Gestational Age | Positive association between cord blood PFHxS and gestational age (β = 0.018; 95% CI: 0.009, 0.028) but exposure prediction studies were not considered reliable or comparable to studies examining developmental effects as the dependent variables
Nian et al. (2022) | Peer review (PFHxS) | Spontaneous abortion (SAB) | Associations were not seen for the main effects (unexplained recurrent SAB), e.g., for quartile 4 (aOR = 1.05) (Table S3), nor was an exposure response gradient evident across the quartiles. Statistically significant associations were also not detected for other stratified analysis but a slight increase in odds was seen among those with BMI >25 (aOR = 1.56; 95% CI: 0.85, 2.84) (Table S7) | No.; The largely null findings from the new study does not change the current draft human evidence synthesis or the developmental effects judgment (i.e., slight).
Hong et al. (2022) | Lit Update | Spontaneous abortion | Association for PFHxS was null for preclinical SABs (OR = 1.04; 95% CI: 0.96, 1.12, Table S13). This is the same population examined in another publication included in the synthesis (Wang et al., 2021) | No.; The largely null findings from the new study does not change the current draft human evidence synthesis or the developmental effects judgment (i.e., slight).
Li et al. (2022b) | Lit Update | Anogenital distance (AGD) | Positive associations between PFHxS and some measures of anogenital distance such as AGD–AF (β = 0.83; 95% CI: 0.16, 1.51), 0.32 (95% CI: 0.05, 0.59), and 0.25 (95% CI: 0.00, 0.51) mm, and AGI–AF, with (β = 0. 22; 95% CI: 0.02, 0.43 mm/kg) | No.; This study with a mix of positive and null associations do not change the current human evidence synthesis or the developmental effects judgment (i.e., slight).
Developmental effects in animals
Yao et al. (2023) | Commenter | Fetal viability in animals | Increased fetal death in mice exposed to highest dose (0.3 mg/kg-day) | Yes.; Findings are supportive of results from a separate animal study that is cited in the draft Toxicological Review. These new findings strengthen the animal evidence synthesis judgement from indeterminate to slight. However, the new findings from this study do not change the overall evidence integration judgement.
Hepatic effects in humans
Borghese et al. (2022) | Lit update | Liver enzymes | Positive association with AST, GGT, and ALP, positive but not statistically significant association with ALT and bilirubin | No.; New studies are consistent with the existing studies and would not change the draft judgment.
Liao et al. (2023) | Lit update | Liver enzymes | Positive association with bilirubin but not ALT, AST, or GGT | No.; New studies are consistent with the existing studies and would not change the draft judgment.
Kim et al. (2023b) | Lit update | Liver enzymes | Positive but not statistically significant associations with ALT, AST, and GGT | No.; New studies are consistent with the existing studies and would not change the draft judgment.
Yao et al. (2020) | Commenter (on PFDA) | Liver enzymes | Positive association with ALT, AST, GGT (statistically significant for GGT) | No.; New studies are consistent with the existing studies and would not change the draft judgment.
Salihović et al. (2019) | Commenter (on PFDA) | Bile acid levels (liver) | Inverse correlations with most bile acids (statistically significant for GDCA) | No.; New studies are consistent with the existing studies and would not change the draft judgment.
Chen et al. (2024) | Peer review | Liver enzymes | No association with liver enzymes. Positive association with apolipoprotein B | No. Study identified after the liver synthesis was updated and would not change the draft judgment of slight.
Yun and Kwon (2023) | Peer review | Liver enzymes | Positive association with ALT, AST, and GGT | No. Study identified after the liver synthesis was updated and would not change the draft judgment of slight.
Rantakokko et al. (2015) | Commenter (on PFDA) | Non-alcoholic fatty liver disease | Inverse association with lobular inflammation (OR = 0.02; 95% CI: <0.01, 0.53 for 2–4 foci per 200× field) | No.; While there are no studies of clinical liver disease available for PFHxS in the current draft, the new studies are inconsistent and would not change the draft judgment of slight for hepatic effects.
Limei et al. (2023) | Lit update | Liver disease | No association with liver problems (OR = 0.97, 95% CI: 0.72, 1.30). Positive but not statistically significant association with ALT
Nilsson et al. (2022b) | Lit update | Liver problems | Positive association with non-alcoholic fatty liver disease in women but not men, with strongest association in postmenopausal women (OR = 2.50, 95% CI: 1.29, 4.85 in Q4 vs. Q1)
Cancer in humans
Jones et al. (2023) | Peer review | Acute lymphatic leukemia | No association with acute lymphatic leukemia in children (OR = 1.04; 95% CI: 0.93, 1.15) per unit increase in log_2_-transformed serum PFHxS | No.; Two studies of different leukemia subtypes showed no association for ALL, and a positive association for CLL/SLL in men, but not women.; One study showed a strong effect on brain cancer risk.; Inconsistent results across the new studies showing increased risk, decreased risk and no association of PFHxS and breast cancer. In addition, one new breast cancer study reports on the same study population as a publication already in the assessment Wielsøe et al. (2017). One previous study reported significantly increased risk of breast cancer among women <= 50 years of age who were estrogen receptor positive; and non-significantly decreased risk of breast cancer among women who were estrogen receptor negative and > 50 years of age. Another study reported strong protective effects with similar effects for both premenopausal and post-menopausal women and for different combinations of estrogen receptor (+/−) and progesterone receptor (+/−). Another study reported significantly decreased risk for some genotypes.; Two studies reporting on liver cancer did not find associations with PFHxS. One study of liver cells showed that PFHxS promoted survival and proliferation at lower concentrations and was cytotoxic at higher concentrations.; One study of prostate cancer showed no association.; One study of renal cancer reported a significant increased association observed for renal cancer that dissipated when controlling for other PFAS and the other reported a significantly decreased risk that did not attenuated when controlling for other PFAS.; One testicular germ cell tumor study reported a very strong effect but was based on 42 cases and 42 controls and included 6 covariates in the regression. Such an analysis would likely stretch the data so far that the model breaks down. For a different PFAS fit using the same covariates, perfluorooctanesulfonamide (PFOSA), the OR = 3404.13; 95% CI: 0.04, 2.69 × 10^8^) which reveals that model is highly unstable and critically deficient. Therefore, the results for PFHxS from this model cannot be taken at face value. Another study of testicular germ cell tumors showed no association.; Three studies reporting on thyroid cancer did not find associations with PFHxS while one study reported an inverse association.; One study that reported on 34 difference cancers in men, in women, and with both sexes together found increased risk in 3/64 estimates which is consistent with chance.; In summary, the available epidemiologic evidence on PFHxS and the risk of cancer remains inadequate; the new studies are not impactful.
Winquist et al. (2023) | Peer review | Chronic lymphatic leukemia/small lymphocytic lymphoma | Among men, there was a positive association between PFHxS concentrations and chronic lymphocytic leukemia/small lymphocytic lymphoma (CLL/SLL) with HR = 1.34 (95% CI: 1.02, 1.75) per doubling of PFHxS, but not among women. No associations with bladder, kidney, pancreas, hematopoietic, breast or prostate cancer by sex or in both sexes
Moon and Mun (2024) | Peer review | Brain cancer | Increased risk of brain cancer with OR = 8.16 (95 % CI: 2.98–68.89) per one-unit increase in ln(PFHxS)
Feng et al. (2022a) | Lit update | Breast cancer | No association with breast cancer (OR = 0.93, 95% CI: 0.79, 1.09) per unit increase in ln-transformed plasma PFHxS levels
Li et al. (2022c) | Lit update | Breast cancer | Decreased risk for breast cancer (OR = 0.73, 95% CI: 0.63, 0.87) per SD increase in ln-transformed PFHxS from the adjusted model – without LASSO (see Table S3)
Wielsøe et al. (2018) | Commenter (on PFDA) | Breast cancer | Increased risk for breast cancer (OR = 5.45, 95% CI: 1.26, 23.8) in high vs. low PFHxS exposure for one genotype
Lee et al. (2020) | Commenter (on PFDA) | Breast cancer | No association of PFHxS with mammographic density, a strong predictor of breast cancer (beta = −0.02, p-value 0.95)
Cohn et al. (2020) | Commenter | Breast cancer | No association with breast cancer (quantitative result not reported)
Itoh et al. (2021) | Peer review | Breast cancer | Decreased risk of breast cancer (OR = 0.21; 95% CI: 0.08, 0.53) per unit log(PFHxS) for highest vs. lowest PFHxS; similar results for both premenopausal and postmenopausal women; and for different combinations of estrogen receptor (+/−) and progesterone receptor (+/−)
Hurley et al. (2018) | Peer review | Breast cancer | Decreased risk of breast cancer (OR = 0.811; 95% CI: 0.596, 1.104) for highest vs. lowest PFHxS; stronger inverse association among postmenopausal women; and for women with negative hormone receptor status
Goodrich et al. (2022) | Lit update | Liver cancer | No association of PFHxS with liver cancer (OR = 1.10; 95% CI: 0.56, 2.30) for PFHxS greater than the 90th% vs. less than 90th%
Cao et al. (2022) | Peer review | Liver cancer | No increased risk of liver cancer (OR = 1.191; 95% CI: 0.903, 1.479)
Sim et al. (2023) | Peer review | Liver cells | PFHxS promoted survival and proliferation at lower concentrations and was cytotoxic at higher concentrations
Rhee et al. (2023) | Peer review | Prostate cancer | No association with prostate cancer OR = 1.04; 95% CI: (0.94,1.14) without other PFAS, and OR = 1.06; 95% CI: (0.94,1.19) with other PFAS
Shearer et al. (2021) | Commenter (on PFDA) | Renal cancer | Increased risk of renal cell carcinoma with PFHxS per unit increase in log_2_-transformed serum PFHxS (OR = 1.27; 95% CI: 1.03, 1.56) that attenuated when controlling for other PFAS (OR = 1.12; 95% CI: 0.88, 1.43)
Wang et al. (2020) | Peer review | Renal cell carcinoma | Decreased risk of renal cell carcinoma (OR = 0.84; 95% CI: 0.74, 0.96) per unit increase in log_2_-transformed serum PFHxS that did not attenuate when controlling for other PFAS (OR = 0.82; 95% CI: 0.69, 0.98)
Lin et al. (2020) | Peer review | Testicular germ cell tumors | Increased risk of germ cell tumors (OR for a 1 ng/L increase in PFHxS was 19.47 (95% CI: 4.20–90.26)
Purdue et al. (2023) | Peer review | Testicular germ cell tumors | No association with PFHxS: OR = 1.1; 95% CI: (0.7, 1.8) without other PFAS; OR = 1.0; 95% CI: (0.5, 1.7 with other PFAS
Alsen et al. (2023) | Peer review | Thyroid cancer | PFHxS not correlated with thyroid cancer incidence (men: r = 0.032; women: r = 0.042)
Li et al. (2023c) | Peer review | Thyroid cancer | No increased odds of thyroid cancer (OR = 0.77; 95% CI: 0.52, 1.15)
Madrigal et al. (2024) | Peer review | Thyroid cancer | PFHxS was inversely associated thyroid cancer OR = 0.82 (95% CI: 0.70–0.97) per unit of log_2_-transformed PFHxS
Alsen et al. (2023) | Peer review | Thyroid cancer | Overall: OR = 1.03 (95% CI: 0.77, 1.37) per doubling of PFHxS. Longitudinal only: OR = 2.10 (95% CI: 1.36–3.37) per doubling of PFHxS
Li et al. (2022a) | Peer review | Multiple cancers | No increased overall risk of cancer was observed. Among men who were highly exposed, out of 31 different cancers, only two showed statistically increased risk (trachea/lung, and bone cancer). Among women who were highly exposed, out of 34 different cancers, only one showed statistically increased risk (thyroid cancer). These results are consistent with chance.
Neurodevelopmental effects in humans
Luo et al. (2022a) | Lit update | Broad neurodevelopmental scale | Inverse but not statistically significant association with cognitive, language, motor, and social-emotional scores, but statistically significant positive association with adaptive behavior score | No.; There is inconsistency for neurodevelopmental effects in the current draft, and the new studies would not influence the draft judgment of slight evidence.
Oh et al. (2022b) | Lit update | Autism, developmental delay | Positive but not statistically significant associations with autism spectrum disorder and developmental delay | No.; There is inconsistency for neurodevelopmental effects in the current draft, and the new studies would not influence the draft judgment of slight evidence.
Zhou et al. (2023) | Lit update | Broad neurodevelopmental scale | Inverse association with communication and motor at 6 mo but inconsistent findings for other measures (problem solving, personal-social) and other visits (2, 12, and 24 mo) | No.; There is inconsistency for neurodevelopmental effects in the current draft, and the new studies would not influence the draft judgment of slight evidence.
Li et al. (2023d) | Lit update | Broad neurodevelopmental scale | Positive association with persistently low trajectory for communication (p < 0.05), gross motor, problem solving ability (p < 0.05), and personal-social skills, but not fine motor | No.; There is inconsistency for neurodevelopmental effects in the current draft, and the new studies would not influence the draft judgment of slight evidence.
Oulhote et al. (2019) | Commenter (on PFDA) | Broad neurodevelopmental scale | Positive association with Boston Naming Test. No association with Strengths and Difficulties Questionnaire. | No.; There is inconsistency for neurodevelopmental effects in the current draft, and the new studies would not influence the draft judgment of slight evidence.
van Larebeke et al. (2022) | Lit update | Broad neurodevelopmental scale | Inverse (favorable) association with incorrect responses on the Continuous Performance Test but not other test results | No.; There is inconsistency for neurodevelopmental effects in the current draft, and the new studies would not influence the draft judgment of slight evidence.
Beck et al. (2023) | Peer review | Broad neurodevelopmental scale | No association with IQ using maternal sample; positive association with childhood sample | No.; There is inconsistency for neurodevelopmental effects in the current draft, and the new studies would not influence the draft judgment of slight evidence.
Xie et al. (2022) | Lit update | Neurobehavior | No association with behavior including externalizing problems | No.; There is inconsistency for neurodevelopmental effects in the current draft, and the new studies would not influence the draft judgment of slight evidence.
Ames et al. (2023) | Lit update | Autism | No association with Social Responsiveness Scale score | No.; There is inconsistency for neurodevelopmental effects in the current draft, and the new studies would not influence the draft judgment of slight evidence.
Kim et al. (2023a) | Lit update | ADHD scale | Positive though non-monotonic association with ADHD rating scale at 8 yr, dependent on age at exposure measurement and sex | No.; There is inconsistency for neurodevelopmental effects in the current draft, and the new studies would not influence the draft judgment of slight evidence.
Vilhelmsson et al. (2023) | Peer review | Cerebral palsy | Positive but not statistically significant associations with cerebral palsy in boys and preterm children | No.; There is inconsistency for neurodevelopmental effects in the current draft, and the new studies would not influence the draft judgment of slight evidence.
Human male reproductive
Luo et al. (2022b) | Lit update | Semen parameters | No association with sperm concentration of motility | No.; Evidence is inconsistent and the new studies would not influence the draft conclusion.
Ma et al. (2021) | Commenter (on PFDA) | Semen parameters | No association sperm concentration, motility, or morphology | No.; Evidence is inconsistent and the new studies would not influence the draft conclusion.
Zhang et al. (2011) | Commenter | Infertility | Lower concentrations of PFHxS in infertile men than worker controls in crude analysis | No.; Evidence is inconsistent and the new studies would not influence the draft conclusion.
Rivera-Núñez et al. (2023) | Lit update | Reproductive hormones | Positive association with T (p < 0.05), no association with free T, E1, E2, E3 | No.; Evidence is inconsistent in existing studies and the new studies would not influence the draft synthesis conclusion of indeterminate evidence.
Guo et al. (2023) | Lit update | Reproductive hormones | No association with testosterone or estradiol (included boys and girls) | No.; Evidence is inconsistent in existing studies and the new studies would not influence the draft synthesis conclusion of indeterminate evidence.
Wang et al. (2023b) | Lit update | Reproductive hormones | Positive association with estradiol but not testosterone (included boys and girls) | No.; Evidence is inconsistent in existing studies and the new studies would not influence the draft synthesis conclusion of indeterminate evidence.
Nian et al. (2020) | Commenter (on PFDA) | Reproductive hormones | No association with total testosterone (beta 0.079, 95% CI: −0.009, 0.166 per ln-unit change), FSH, or LH | No.; Evidence is inconsistent in existing studies and the new studies would not influence the draft synthesis conclusion of indeterminate evidence.
Human female reproductive
Hong et al. (2022) | Lit update | In vitro fertilization outcomes | No association with oocyte maturation rate, fertilization rate, high quality embryo rate. Inverse but not statistically significant (OR=0.60, 95% CI: 0.12, 2.96) for clinical pregnancy | No.; Evidence of an association with fecundity and infertility is inconsistent across new studies and was similarly inconsistent across existing studies. The conclusion of indeterminate evidence would likely remain the same.
Cohen et al. (2023) | Lit update | Fecundity, pregnancy | No association with time to pregnancy or odds of clinical pregnancy
Luo et al. (2022c) | Lit update | Fecundity, infertility | Lower odds of infertility (OR 0.61, 95% CI: 0.45, 0.82) and higher fecundability
Tan et al. (2022) | Lit update | Infertility | Lower odds of infertility (non-monotonic across quartiles and not statistically significant)
Whitworth et al. (2016) | Commenter (on PFDA) | Fecundity | No association (FR 0.97, 95% CI: 0.90, 1.1)
Björvang et al. (2021) | Peer review | Ovarian reserve | No association with Anti-Mullerian hormone or atretic follicles in ovarian cortical tissues
Ma et al. (2021) | Commenter (on PFDA) | In vitro fertilization outcomes, pregnancy | Fewer zygotes and good quality embryos with higher exposure; no association with clinical pregnancy
Zeng et al. (2023b) | Peer review | In vitro fertilization outcomes | Lower high quality embryo rate with exposure-response gradient across three categories of exposure
Petro et al. (2014) | Commenter | In vitro fertilization outcomes | Positive association with fertilization rate in crude analysis
Wang et al. (2019) | Commenter (on PFDA) | Polycystic ovarian syndrome | Positive but not statistically significant association with PCOS-related infertility (OR 2.08, 95% CI: 0.88, 4.93 in 3rd vs. 1st tertile) | No.; Existing evidence on gynecological conditions is inconsistent and there is considerable uncertainty due to potential reverse causation. The new studies do not inform this uncertainty.
Mitro et al. (2023) | Peer review | Uterine fibroids | Positive but not statistically significant association with total fibroid volume | No.; Existing evidence on gynecological conditions is inconsistent and there is considerable uncertainty due to potential reverse causation. The new studies do not inform this uncertainty.
Rivera-Núñez et al. (2023) | Lit update | Reproductive hormones | Positive association with E1, E2, E3 (p < 0.05), no association with T, FT | No.; New studies would not change the current draft judgment.
Nian et al. (2020) | Commenter (on PFDA) | Reproductive hormones | No association with total testosterone (beta −0.029, 95% CI: −0.090, 0.032 per ln-unit change), FSH, or LH | No.; New studies would not change the current draft judgment.
Liu et al. (2020a) | Commenter (on PFDA) | Reproductive hormones | Positive association with estradiol (6.8% change, 95% CI: 2.2, 11.6) | No.; New studies would not change the current draft judgment.
Averina et al. (2024) | Peer review | Pubertal development | No association with age at menarche | No.; New studies would not change the current draft judgment.
Ding et al. (2020) | Commenter | Menopause | No association with timing of incident natural menopause
Taylor et al. (2014) | Commenter | Menopause | Higher odds of menopause with exposure response gradient across tertiles.
Lin et al. (2022) | Lit update | Postpartum hemorrhage | Higher odds of postpartum hemorrhage (OR 3.42, 95% CI: 1.45, 8.07) | No.; Single study of the outcome and evidence is not strong enough to increase certainty in the evidence for female reproductive effects.
Kim et al. (2020) | Commenter | Breastfeeding | Inverse association in crude analysis with PFHxS modeled as outcome | Evidence for lactation duration will be evaluated and considered for inclusion in the assessment.
Papadopoulou et al. (2016) | Commenter | Breastfeeding | Positive but not statistically significant association with breastfeeding duration | Evidence for lactation duration will be evaluated and considered for inclusion in the assessment.
Urinary effects in humans
Nilsson et al. (2022b) | Lit update | Kidney disease, urate | No association with kidney disease (OR 0.90, 95% CI: 0.76, 1.08) or urate | No.; Existing studies are inconsistent with considerable uncertainty due to potential reverse causation. The new studies do not inform this uncertainty.
Liang et al. (2023) | Lit update | Glomerular filtration rate | Higher GFR (not statistically significant) | No.; Existing studies are inconsistent with considerable uncertainty due to potential reverse causation. The new studies do not inform this uncertainty.
Sood et al. (2019) | Commenter (on PFDA) | Glomerular filtration rate | Inverse but not statistically significant association with eGFR (beta −10.3, 95% CI: −23.6, 3.0) | No.; Existing studies are inconsistent with considerable uncertainty due to potential reverse causation. The new studies do not inform this uncertainty.
Pan et al. (2017) | Commenter | Glomerular filtration rate | Inverse association with GFR in crude analysis | No.; Existing studies are inconsistent with considerable uncertainty due to potential reverse causation. The new studies do not inform this uncertainty.
He et al. (2023) | Peer review | Creatinine, uric acid | Positive association with uric acid (non-monotonic across quartiles). No association with creatinine. | No.; Existing studies are inconsistent with considerable uncertainty due to potential reverse causation. The new studies do not inform this uncertainty.
Feng et al. (2022b) | Lit update | Hyperuricemia | No association with hyperuricemia | No.; Existing studies are inconsistent with considerable uncertainty due to potential reverse causation. The new studies do not inform this uncertainty.
Arrebola et al. (2019) | Commenter (on PFDA) | Hyperuricemia | Positive but not statistically significant association with hyperuricemia (OR 1.33, 95% CI: 0.70, 2.54) | No.; Existing studies are inconsistent with considerable uncertainty due to potential reverse causation. The new studies do not inform this uncertainty.
Yao et al. (2020) | Commenter (on PFDA) | Uric acid | Positive association with uric acid (beta 8.44, 95% CI: 2.17, 15.09) | No.; Existing studies are inconsistent with considerable uncertainty due to potential reverse causation. The new studies do not inform this uncertainty.
Cardiometabolic effects in humans
Haug et al. (2023) | Lit update | Serum lipids | No association with HDL or LDL cholesterol | No.; Mixed results from the new studies would not change the current draft judgment.
Donat-Vargas et al. (2019b) | Commenter (on PFDA) | Serum lipids, hypertension | No association with total cholesterol, triglycerides, or hypertension | No.; Mixed results from the new studies would not change the current draft judgment.
Batzella et al. (2022) | Lit update | Serum lipids | Positive association with total cholesterol (beta 1.74, 95% CI: 1.36, 2.13) and LDL-cholesterol | No.; Mixed results from the new studies would not change the current draft judgment.
Morgan et al. (2023) | Lit update | Serum lipids | No association with total cholesterol or LDL-cholesterol (crude analysis only) | No.; Mixed results from the new studies would not change the current draft judgment.
Rosen et al. (2022) | Lit update | Serum lipids | Positive but not statistically significant association with total cholesterol, LDL, and triglycerides | No.; Mixed results from the new studies would not change the current draft judgment.
Fan et al. (2020) | Commenter | Serum lipids | No association with total or LDL cholesterol or triglycerides | No.; Mixed results from the new studies would not change the current draft judgment.
Li et al. (2019) | Commenter | Serum lipids | No association with total cholesterol or triglycerides | No.; Mixed results from the new studies would not change the current draft judgment.
Aker et al. (2023) | Peer review | Serum lipids, prediabetes | No association with total cholesterol, LDL, or prediabetes | No.; Mixed results from the new studies would not change the current draft judgment.
Kang et al. (2023) | Peer review | Serum lipids | Positive association with high and medium vs. low trajectory for total cholesterol and LDL cholesterol | No.; Mixed results from the new studies would not change the current draft judgment.
Faquih et al. (2024) | Peer review | Serum lipids | Positive association with total cholesterol. | No.; Mixed results from the new studies would not change the current draft judgment.
Nilsson et al. (2022b) | Lit update | Serum lipids, blood pressure, cardiovascular disease | Positive association with total cholesterol and LDL-cholesterol in cross-sectional but not prospective analysis. No association with high blood pressure (OR 0.92, 95% CI: 0.83, 1.03) or cardiovascular disease (OR 0.96, 95% CI: 0.81, 1.15) | No.; Mixed results from the new studies would not change the current draft judgment.
Boafo et al. (2023) | Peer review | Serum lipids, blood pressure, cardiovascular disease risk | Inverse association with systolic blood pressure, positive association with HDL. No association with diastolic blood pressure, LDL, total cholesterol, triglycerides, or Framingham risk score. | No.; Mixed results from the new studies would not change the current draft judgment.
Fassler et al. (2019) | Commenter | Serum lipids, adiposity, insulin resistance | No association with BMI, insulin resistance, or serum lipids | No.; Mixed results from the new studies would not change the current draft judgment.
Yao et al. (2020) | Commenter (on PFDA) | Serum lipids, blood glucose | Positive association with total cholesterol (beta 6.98, 95% CI: 3.06, 11.14), triglycerides, and blood glucose | No.; Mixed results from the new studies would not change the current draft judgment.
Chen et al. (2020b) | Commenter | Serum lipids, insulin resistance, adiposity | Positive but not statistically significant association with total and LDL cholesterol and blood glucose. Inverse association with BMI and body fat percent. | No.; Mixed results from the new studies would not change the current draft judgment.
Jain (2014) | Commenter | Serum lipids, adiposity | No association with total cholesterol, triglycerides, or BMI | No.; Mixed results from the new studies would not change the current draft judgment.
Ding et al. (2022) | Lit update | Hypertension | No association with hypertension (HR 0.98, 95% CI: 0.93, 1.04 per 2-fold increase) | No.; Mixed results from the new studies would not change the current draft judgment.
Mitro et al. (2020a) | Lit update | Blood pressure | No association with blood pressure, BMI, waist circumference, mid-upper arm circumference, or skinfold thickness | No.; Mixed results from the new studies would not change the current draft judgment.
Xu et al. (2023b) | Peer review | Blood pressure | No association with blood pressure in early childhood. | No.; Mixed results from the new studies would not change the current draft judgment.
Ma et al. (2019) | Commenter | Blood pressure | No association with blood pressure | No.; Mixed results from the new studies would not change the current draft judgment.
Sood et al. (2019) | Commenter (on PFDA) | Blood pressure | No association with blood pressure (beta 0.3, 95% CI: −0.1, 0.7) | No.; Mixed results from the new studies would not change the current draft judgment.
Lind et al. (2018) | Commenter (on PFDA) | Carotid artery intima-media thickness | Positive association with IMT thickness (beta 0.015, 95% CI: 0.005, 0.0025) | No.; These results support coherence with serum lipids but would not change the current draft judgment.
Li et al. (2023b) | Lit update | Cardiovascular disease | No association with acute coronary syndrome | No.; New studies contribute to existing inconsistency and would not change the current draft judgment.
Hutcheson et al. (2020) | Commenter | Stroke | Inverse association with stroke in participants with diabetes (OR 0.75, 95% CI: 0.64–0.88), no association in participants without diabetes | No.; New studies contribute to existing inconsistency and would not change the current draft judgment.
Zeng et al. (2022) | Commenter | Cardiorespiratory fitness | Inverse but not statistically significant association with cardiorespiratory fitness. | No.; Single study on the outcome would not change the current draft judgment.
Yang et al. (2022) | Lit update | Gestational hypertension | Lower odds of gestational hypertension (OR 0.66, 95% CI: 0.35, 1.24) and lower continuous blood pressure | No.; New studies contribute to existing inconsistency and would not change the current draft judgment.
Huo et al. (2020) | Lit update | Gestational hypertension | No association with gestational hypertension (OR 0.80, 95% CI: 0.44, 1.47) or preeclampsia (OR 1.05, 95% CI: 0.60, 1.83) | No.; New studies contribute to existing inconsistency and would not change the current draft judgment.
Zhu and Bartell (2022) | Lit update | Gestational hypertension | Small positive association with hypertensive disorders in pregnancy (OR 1.03, 95% CI: 1.02, 1.04) | No.; New studies contribute to existing inconsistency and would not change the current draft judgment.
Xu et al. (2022) | Lit update | Gestational diabetes | Inverse association with gestational diabetes (OR 0.09, 95% CI: 0.03, 0.22 in third tertile), inverse association with continuous glucose levels in oral glucose tolerance test | No.; Existing studies are inconsistent and new studies would not change the current draft judgment.
Zhang et al. (2023a) | Lit update | Gestational diabetes | Positive association with gestational diabetes (OR 3.46, 95% CI: 1.64, 6.30 in 3rd tertile) | No.; Existing studies are inconsistent and new studies would not change the current draft judgment.
Xu et al. (2020a) | Lit update | Gestational diabetes | No association with gestational diabetes (OR 0.79, 95% CI: 0.46, 1.31 in Q4 vs. Q1) | No.; Existing studies are inconsistent and new studies would not change the current draft judgment.
Preston et al. (2020) | Lit update | Gestational diabetes | No association with gestational diabetes | No.; Existing studies are inconsistent and new studies would not change the current draft judgment.
Liu et al. (2019) | Commenter | Gestational diabetes | No association with gestational diabetes in crude analysis | No.; Existing studies are inconsistent and new studies would not change the current draft judgment.
Zhang et al. (2023a) | Peer review | Gestational diabetes | Positive association with gestational diabetes with exposure-response gradient across tertiles. | No.; Existing studies are inconsistent and new studies would not change the current draft judgment.
Li et al. (2020) | Commenter (on PFDA) | Gestational blood glucose | Positive but not statistically significant association with blood glucose in oral glucose tolerance test (beta 0.07, 95% CI: −0.06, 0.21) | No.; Existing studies are inconsistent and new studies would not change the current draft judgment.
Dunder et al. (2023) | Lit update | Blood glucose | No association with blood glucose | No.; Existing and new studies are primarily null and would not change the current draft judgment.
Christensen et al. (2016) | Commenter (on PFDA) | Diabetes | No association with diabetes (OR 0.98, 95 % CI 0.69, 1.16) or pre-diabetes (OR 1.00, 95% CI: 0.77, 1.16) | No.; Existing and new studies are primarily null and would not change the current draft judgment.
Park et al. (2022) | Lit update | Diabetes | Positive association with incident diabetes (OR 1.58, 95% CI: 1.13, 2.21 in T3 vs. T1) but not monotonic across tertiles | No.; Existing and new studies are primarily null and would not change the current draft judgment.
Cardenas et al. (2019) | Commenter | Diabetes | No association with incident diabetes in a cohort of participants from a diabetes prevention trial. | No.; Existing and new studies are primarily null and would not change the current draft judgment.
Zong et al. (2016) | Commenter | Diabetes | No association with diabetes | No.; Existing and new studies are primarily null and would not change the current draft judgment.
Donat-Vargas et al. (2019a) | Commenter (on PFDA) | Diabetes risk, insulin resistance | No increase in diabetes risk or HOMA-IR | No.; Existing and new studies are primarily null and would not change the current draft judgment.
Kim et al. (2015) | Commenter (on PFDA) | Insulin resistance | No association with HOMA (beta −0.08, 95% CI: −0.68, 0.52) | No.; Existing and new studies are primarily null and would not change the current draft judgment.
Mehta et al. (2021) | Commenter (on PFDA) | Insulin resistance | No association with blood glucose or HOMA-IR | No.; Existing and new studies are primarily null and would not change the current draft judgment.
Bassler et al. (2019) | Commenter | Insulin resistance | Inverse association with insulin | No.; Existing and new studies are primarily null and would not change the current draft judgment.
Brosset and Ngueta (2022) | Lit update | Glycemic control | No association with poor glycemic control | No.; Existing and new studies are primarily null and would not change the current draft judgment.
Ye et al. (2021) | Commenter (on PFDA) | Metabolic syndrome | No association with metabolic syndrome (OR 1.02, 95% CI: 0.93, 1.13) or blood glucose, blood pressure, serum lipids, or waist circumference | No. Existing and new studies are primarily null and would not change the current draft judgment.
Leary et al. (2020) | Commenter | Metabolic syndrome | No association with metabolic syndrome in firefighters | No. Existing and new studies are primarily null and would not change the current draft judgment.
Schillemans et al. (2022) | Lit update | Adiposity | No association with BMI z-score | No. Existing and new studies are primarily null and would not change the current draft judgment. The majority of additional studies are intended to examine determinants of PFHxS concentrations and/or are crude analyses without adjustment for potential confounders.
Zeng et al. (2023a) | Lit update | Adiposity | No association with BMI z-score trajectory
Harris et al. (2017) | Commenter (on PFDA) | Adiposity | Lower PFHxS levels in obese (−8.0% difference, 95% CI: −26.6, 15.2 for obese vs. normal)
Ji et al. (2012) | Commenter (on PFDA) | Adiposity | Higher PFHxS concentrations in overweight participants, but no statistical analysis
Pirard et al. (2020) | Commenter (on PFDA) | Adiposity | No association with BMI (quantitative results not presented)
Liu et al. (2020b) | Commenter (on PFDA) | Adiposity | No association with BMI
Liu et al. (2020e) | Peer review | Adiposity | Positive association with some measures of adiposity at birth but the effect decreases over follow-up period.
Kim et al. (2020) | Commenter | Adiposity | No association with pre-pregnancy BMI in crude analysis with PFHxS modeled as outcome
Bjerregaard-Olesen et al. (2016) | Commenter | Adiposity | No association with pre-pregnancy BMI in analysis with PFHxS modeled as outcome
Chang et al. (2020) | Commenter | Adiposity | Inverse association with BMI in analysis with BMI modeled as outcome
Cardenas et al. (2018) | Commenter | Adiposity | Positive but not statistically significant association with some measures of adiposity including skinfold thickness and subcutaneous fat
Colles et al. (2020) | Commenter | Adiposity | No association with BMI in analysis with PFHxS modeled as outcome
Eick et al. (2021) | Commenter | Adiposity | No association with BMI in crude analysis
Fisher et al. (2016) | Commenter | Adiposity | No association with BMI in descriptive analysis
Han et al. (2018) | Commenter | Adiposity | No association with BMI (quantitative results not reported)
Hölzer et al. (2008) | Commenter | Adiposity | No association with BMI in crude analysis
Huang et al. (2019a) | Commenter | Adiposity | No association with BMI in analysis with PFHxS modeled as outcome
Koponen et al. (2018) | Commenter | Adiposity | No association with BMI in crude correlation analysis (quantitative result not reported)
Lewin et al. (2017) | Commenter | Adiposity | No association with BMI in crude analysis
Mehta et al. (2020) | Commenter | Adiposity | No association with BMI
Nair et al. (2021) | Commenter | Adiposity | No association with BMI in crude analysis
Ramli et al. (2020) | Commenter | Adiposity | No association with BMI in analysis with PFHxS modeled as outcome
Rylander et al. (2009) | Commenter | Adiposity | No association with BMI (quantitative result not reported)
Tsai et al. (2018) | Commenter | Adiposity | No association with BMI (unadjusted means)
Yang et al. (2019) | Commenter | Adiposity | Higher PFHxS concentration with higher BMI (unadjusted means)
Tian et al. (2019b) | Commenter | Adiposity | No association with BMI or waist circumference
Brantsæter et al. (2013) | Commenter | Adiposity, gestational weight gain | Higher PFHxS concentrations with higher BMI (unadjusted means), no association with weight change
Mitro et al. (2020b) | Commenter | Gestational weight gain | No association with gestational weight gain; positive but not statistically significant association with postpartum weight retention
Thyroid effects in humans
Jensen et al. (2022) | Lit update | Thyroid hormones | No association with free T4, association with TSH was positive but not statistically significant (beta 4.05, 95% CI: −1.58, 10.00) | No. Existing and new studies are inconsistent and would not change the current draft judgment.
Derakhshan et al. (2022) | Lit update | Thyroid hormones | Positive association with free T4 (beta 0.13, 95% CI: −0.01, 0.28) but no association with TSH or free T3 | No. Existing and new studies are inconsistent and would not change the current draft judgment.
Li et al. (2023a) | Lit update | Thyroid hormones | No association with TSH or free T4 | No. Existing and new studies are inconsistent and would not change the current draft judgment.
Tillaut et al. (2022) | Lit update | Thyroid hormones | No association with free T4, free T3, or TSH | No. Existing and new studies are inconsistent and would not change the current draft judgment.
Wang et al. (2023b) | Lit update | Thyroid hormones | Positive association with total T4 but not other thyroid hormones. | No. Existing and new studies are inconsistent and would not change the current draft judgment.
Jain and Ducatman (2019) | Commenter (on PFDA) | Thyroid hormones | Positive association with Total T3 in participants at higher glomerular filtration stages. | No. Existing and new studies are inconsistent and would not change the current draft judgment.
Xie et al. (2024) | Peer review | Thyroid hormones | Positive association with free T3 but not free T4. | No. Existing and new studies are inconsistent and would not change the current draft judgment.
Hu et al. (2023) | Peer review | Thyroid hormones | Positive association with TSH with exposure measurement in cord blood. | No. Existing and new studies are inconsistent and would not change the current draft judgment.
Freire et al. (2023) | Peer review | Thyroid hormones | No clear associations with T4, T3, or TSH. | No. Existing and new studies are inconsistent and would not change the current draft judgment.
Dufour et al. (2020) | Commenter (on PFDA) | Thyroid disease | Inverse association with hyperthyroidism (OR 0.14, 95% CI: 0.03, 0.63) | No. Existing and new studies are inconsistent and would not change the current draft judgment.
Christensen et al. (2016) | Commenter (on PFDA) | Thyroid disease | Inverse association with thyroid disease (OR 0.59, 95% CI: 0.20, 1.06) | No. Existing and new studies are inconsistent and would not change the current draft judgment.
Nilsson et al. (2022b) | Lit update | Thyroid problems, thyroid hormones | No association with thyroid problems (OR 0.94, 95% CI: 0.73, 1.21). Inverse but not statistically significant association with T4 but not T3 or TSH | No. Existing and new studies are inconsistent and would not change the current draft judgment.
Other effects in humans
Højsager et al. (2022) | Lit update | Bone mineral density | Inverse association with bone mineral content and density (p>0.05), stronger in boys | Yes. Peer reviewers recommended inclusion of bone mineral density and osteoporosis in the assessment, so these studies and others identified by the literature search and peer review were synthesized.
Zhao et al. (2022) | Lit update | Bone mineral density | Inverse association (p>0.05) with femur bone mineral density in women without menopause/hysterectomy | Yes. Peer reviewers recommended inclusion of bone mineral density and osteoporosis in the assessment, so these studies and others identified by the literature search and peer review were synthesized.
Colicino et al. (2020) | Lit update | Bone mineral density | No association with lumbar spine or femur density | Yes. Peer reviewers recommended inclusion of bone mineral density and osteoporosis in the assessment, so these studies and others identified by the literature search and peer review were synthesized.
Xiong et al. (2022) | Lit update | Bone mineral density | Positive association with femur density and inverse association with lumbar spine density in girls only | Yes. Peer reviewers recommended inclusion of bone mineral density and osteoporosis in the assessment, so these studies and others identified by the literature search and peer review were synthesized.
Blomberg et al. (2022) | Lit update | Bone mineral density | No association with bone mineral density in children to 9 years | Yes. Peer reviewers recommended inclusion of bone mineral density and osteoporosis in the assessment, so these studies and others identified by the literature search and peer review were synthesized.
Fan et al. (2023) | Lit update | Bone mineral density, osteoporosis | Positive but not statistically significant association with osteoporosis (OR 1.23, 95% CI: 0.95, 1.60), inverse association with bone mineral density (beta −0.23, 95% CI: −0.33, −0.12) | Yes. Peer reviewers recommended inclusion of bone mineral density and osteoporosis in the assessment, so these studies and others identified by the literature search and peer review were synthesized.
Xu et al. (2023a) | Peer review | Osteoporotic fractures | No PFHxS specific estimate, but high contamination included PFHxS. Positive association with osteoporotic fractures. | Yes. Peer reviewers recommended inclusion of bone mineral density and osteoporosis in the assessment, so these studies and others identified by the literature search and peer review were synthesized.
Shiue (2015d) | Commenter (on PFDA) | Oral health | No association with teeth health, ache, tooth loss | No. No association in single study.
Liao et al. (2022a) | Lit update | Hematology | Positive but not statistically significant association with gestational anemia in the 1st and 3rd but not 2nd trimesters. No association with hemoglobin concentration during pregnancy | No.; Inconsistent results in new studies. Evidence would be indeterminate overall.
Cui et al. (2022) | Lit update | Hematology | Positive association with hematocrit (3.51% change, 95% CI: 1.82, 5.24) and hemoglobin (3.14% change, 95% CI: 1.33, 4.99) during pregnancy | No.; Inconsistent results in new studies. Evidence would be indeterminate overall.
Liu et al. (2022) | Lit update | Hematology | No association with white blood cells and lymphocytes | No.; Inconsistent results in new studies. Evidence would be indeterminate overall.
Shiue (2015a) | Commenter (on PFDA) | Neurologic; Remembering condition | No association with difficulty remembering (RR 0.45, 95% CI: 0.25–0.81 for >3 times per week) | No.; Lack of association in available studies and would be indeterminate overall.
Shiue (2015b) | Commenter (on PFDA) | Neurologic; Depression | No association with adult depression | No.; Lack of association in available studies and would be indeterminate overall.
Shiue (2015c) | Commenter (on PFDA) | Neurologic; Hearing disturbance | No association with trouble hearing | No.; Lack of association in available studies and would be indeterminate overall.
Gaylord et al. (2019) | Commenter (on PFDA) | Pulmonary function | No association with FEV or FVC (FEV1 beta −0.01, 95% CI: −0.10, 0.08, FVC beta 0.03, 95% CI: −0.08, 0.13) | No.; Lack of association in available studies and would be indeterminate overall.
Shi et al. (2023) | Lit update | Pulmonary function | No association with forced expiratory volume or forced volume capacity | No.; Lack of association in available studies and would be indeterminate overall.
ADME/PK studies
Chiu et al. (2022) | Lit update | One-compartment PK model fit to data from highly exposed communities (after intervention) | GM (95% CI) for t1/2, Vd and CL are 8.30 (5.38–13.5) yr, 0.29 (0.17–0.45) L/kg and 0.068 (0.033–0.107) mL/kg-d. The CL is higher than our previous GM and health-protective lower bound, but in the range of other studies. | Yes.; Incorporated clearance value into calculation of overall average clearance. See Section 3.1 in main document
Jain and Ducatman (2022) | Lit update | PFHxS serum levels in US females vs. males as a function of age (NHANES). | In males a slow, steady increase from age 12 to ≥75, but in females the levels decline from age 12 to 30, reaching ~ ½ the levels in males, then begin to increase around age 45. | Yes.; Semi-quantitative support for impact of menstrual fluid loss: data are consistent with estimated clearance values. Including *mean* non-menstrual clearance. See Section 3.1 in main document
Oh et al. (2022a) | Lit update | Change in maternal PFHxS levels from conception to 2 yr post-partum | Mean PFHxS serum levels decline slightly (0.6%) during pregnancy, decline 5.6% (statistically significant) from 0–6 mo post-partum, then increase 0.5% from 6–24 mo post-partum. | Yes.; Maternal concentrations at or below concentration at conception: should be predicted with menstrual clearance included. See Section 3.1 in main document
Li et al. (2022d) | Lit update | PFHxS half-life in Swedish population after end of high drinking water exposure. | Mean (95% CI) t1/2 = 4.52 (4.14, 4.99) y. Median (5th, 95th %tile) = 5.4 (2.34, 9.29) y. This is a bit shorter than some other studies but overlap to a fair extent. Results may be less impacted by ongoing background exposure than other data. | Yes.; Incorporated clearance (from reported half-life) into calculation of overall average clearance. See Section 3.1 in main document
Nilsson et al. (2022a) | Lit update | PFHxS half-lives in Australian firefighters after change in foam formulation. | Mean (95% CI) t1/2 estimated to be 7.8 (7.3, 8.3) yr. Rate of decline vs. initial serum level also evaluated and appeared to be independent. Mean t1/2 in high exposure group was 7.7 yr vs. 8.2 yr in low exposure group. | Yes.; Incorporated clearance (from reported half-life) into calculation of overall average clearance. See Section 3.1 in main document
Lynch et al. (2023) | Commenter on PFHxS | Available PK models. | Citation not added as it does not meet our inclusion criteria. | Lynch et al. (2023) is an application of a previously published model (Chiu et al., 2022) and does not represent new PK science: neither the underlying model nor the parameters are different. Therefore, it does not meet our inclusion criteria for PK models.
Mechanistic, including non-PECO routes of exposure
Solan et al. (2023) | Lit Update | Neurotoxicity/hepatot oxicity | Every short-chain PFAS evaluated, except for PFHxS, increased the activity of at least one antioxidant enzyme. | No.; Results would not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced neuro or liver toxicity.
Phelps et al. (2023) | Lit Update | Immune | PFHxS and GenX suppressed the respiratory burst in zebrafish and human neutrophil-like cell line. | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced immunotoxicity.
Stoker et al. (2023) | Lit Update | Thyroid | PFOS & PFHxS found to be NIS inhibitors | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced thyroid toxicity.
Leclercq et al. (2022) | Lit Update | Female reproductive/ Developmental | PFAS exposure during IVM, PFHxS tended to result in higher blastocyst rates on day 5 post fertilization and on day 6 post fertilization as well as in higher apoptosis rates in blastocysts. PFHxS resulted in higher total cell counts in blastocysts. | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced developmental or female reproductive effects.
Hvizdak et al. (2023) | Lit Update | Developmental | Study demonstrates that of the six PFAS tested, PFOA, PFOS, PFNA, and PFHxS bind to and inhibit CYP3A7. CYP3A7 is responsible for facilitating a variety of reactions essential for fetal development. | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced developmental effects.
Fragki et al. (2023) | Lit update | Hepatic | PFAS, including PFHxS, may lead to interference of hepatic gene expression and lipid metabolism. | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced hepatic effects.
Gundacker et al. (2022) | Lit Update | Developmental | Potential MOAs of reduced birthweight associated with PFAS identified. | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced developmental effects.
Amstutz et al. (2022) | Lit Update | ADME | PFAS inhibition of CYP. | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced toxicity.
Søderstrøm et al. (2022) | Lit Update | Hepatic | PFAS modulation of PPAR-signaling pathway in Atlantic cod fish. | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced hepatic effects
Hallberg et al. (2022) | Lit Update | Female reproductive | PFHxS induction of phenotypic, transcriptomic, and DNA methylation in bovine oocytes | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced female reproductive effects.
Evans et al. (2022) | Lit Update | Hepatic | Characterization of PPAR alpha and hER binding to PFAS | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced hepatic effects.
Qin et al. (2023a) | Lit Update | Other | Characterization of PFHxS protein binding | No; Results do not change draft judgements or provide additional insight into the dosimetric extrapolation approach.
Behr et al. (2018) | Lit Update | Reproductive toxicity/ Endocrine | Examination of endocrine properties of various PFAS including PFHxS | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced reproductive effects.
Ishibashi et al. (2019) | Lit Update | Hepatic | PFAS binding to human and Balkal seal PPAR alpha | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced hepatic effects.
Annunziato et al. (2019) | Lit Update | Developmental | PFAS developmental effects on behavioral, morphometric and gene expression endpoints in zebrafish. | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced developmental effects.
Vogs et al. (2019) | Lit Update | ADME | Toxicokinetics of PFAS uptake in zebrafish | No.; While these results may be of interest in further work in zebrafish, these results are not directly applicable to humans or mammalian model species.
Pan et al. (2019) | Lit Update | Other | Human bone mesenchymal stem cells (hBMSCs) were used to evaluate the effects of Cl-PFESA at non-cytotoxic concentrations on molecular regulation and cellular function of stem cells compared to PFOS, perfluorohexane sulfonate (PFHxS) and perfluorooctanoic acid (PFOA). | No, results do not influence draft judgments or provide key insights into key science issues, nor do they provide additional insights into potential mechanisms of PFHxS-induced effects.
Hoover et al. (2019) | Lit Update | Other | Examination of the cytotoxicity of PFAS singly and in binary mixtures using an amphibian fibroblast cell line. Second, we used this experimental data to develop quantitative structure-activity relationship (QSAR) models for single and binary mixtures. | No, results do not influence draft judgments or provide key insights into key science issues, nor do they provide additional insights into potential mechanisms of PFHxS-induced effects.
Sørli et al. (2020) | Lit Update | Respiratory Toxicity/Other | In vitro models to assess toxicity to the respiratory system; i) a lung surfactant (LS) function assay to assess the acute inhalation toxicity potential, and ii) a cell model with human bronchial epithelial cells to study pro-inflammatory potential and modulation of inflammatory responses. PFHxS, PFOA and PFOS can inhibit LS function. | No, results do not influence draft judgments or provide key insights into key science issues, nor do they provide additional insights into potential mechanisms of PFHxS-induced respiratory or other effects.
Menger et al. (2020) | Lit Update | Neurotoxicity | PFHxS behavioral effects and bioaccumulation in zebrafish | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced neurotoxicity effects.
Buckalew et al. (2020) | Lit Update | Thyroid | Evaluation of PFAS sodium-iodide symporter (NIS) inhibitors | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced thyroid toxicity.
Liu et al. (2020d) | Lit Update | Developmental | Evaluation the toxicity of several short chain PFAS in hMSC. Results demonstrated cytotoxic and potential developmental toxicity. | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced developmental effects.
Xu et al. (2020b) | Lit Update | Other | Effects of PFAS exposure on serum microRNAs | No, results do not influence draft judgments or provide key insights into key science issues, nor do they provide additional insights into potential mechanisms of PFHxS-induced effects.
Ojo et al. (2020) | Lit Update | Hepatic | PFAS mixtures effects on HepG2 cells | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced hepatic effects.
Gaballah et al. (2020) | Lit Update | Developmental; developmental neurotoxicity | Evaluation of developmental and neurodevelopmental toxicity from PFAS exposure | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced developmental effects and or neurodevelopmental effects.
Ojo et al. (2021) | Lit Update | Hepatoxicity | Evaluation of oxidative stress caused by individual and combined PFAS on human liver cells | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced hepatic effects.
Bjork et al. (2021) | Lit Update | Hepatotoxicity | Evaluation of binary mixtures of PFAS on molecular responses. PPAR alpha activation was observed in FAO rat hepatoma cells exposed to binary mixtures of PFAS. | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced hepatic effects.
Modaresi et al. (2021) | Lit Update | Other | PFAS augment adipogenesis in 3T3-L1 adipocytes | No, results do not influence draft judgments or provide key insights into key science issues, nor do they provide additional insights into potential mechanisms of PFHxS-induced effects.
Park et al. (2021) | Lit Update | Immune | Examination of the effects of PFAS, including PFHxS, on mast cell-mediated inflammatory responses using in vitro mouse bone marrow-derived mast cells (BMMCs) and human mast cells (HMC-1) and in vivo mice model. | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced immunotoxicity.
Mann et al. (2021) | Lit Update | Other | Use of human fatty acid binding protein to detect PFAS. | No, results do not influence draft judgments or provide key insights into key science issues, nor do they provide additional insights into potential mechanisms of PFHxS-induced effects.
Xu et al. (2021) | Lit Update | Developmental | Lipid profiling during different stages of zebrafish development to understand PFHxS toxicity | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced developmental effects.
Ishibashi et al. (2011) | Lit Update | Hepatic | PPAR alpha activation in Baikal seal by PFAS | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced hepatic effects
Vongphachan et al. (2011) | Lit Update | Neurodevelopmental; Thyroid | PFAS effects on mRNA expression levels of thyroid-responsive genes in avian primary cultures | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced neurodevelopmental or thyroid effects
Berntsen et al. (2018) | Lit Update | Neuro | PFAS effects on viability and NMDA receptor activation | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced neurodevelopmental effects
Wallace et al. (2013) | Lit Update | Hepatic | PFAS structure activity relationships and interference with mitochondrial respiration in rat liver | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced hepatic effects
Wang et al. (2018) | Lit Update | Other | Stabilization of liposomes by PFAS | No, results do not influence draft judgments or provide key insights into key science issues, nor do they provide additional insights into potential mechanisms of PFHxS-induced effects.
Qiu et al. (2020) | Lit Update | Female Repro; Other | PFAS binding to estrogen receptors | No, results do not influence draft judgments or provide key insights into key science issues, nor do they provide additional insights into potential mechanisms of PFHxS-induced effects.
Qin et al. (2020) | Lit Update | Cardiometabolic effects; Diabetes | Stimulation of insulin secretion by Islet beta cells caused by PFAS | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced cardiometabolic effects
Nguyen et al. (2020) | Lit Update | Other | Inhibition of carbonic anhydrases by PFAS | No, results do not influence draft judgments or provide key insights into key science issues, nor do they provide additional insights into potential mechanisms of PFHxS-induced effects.
Dasgupta et al. (2020) | Lit Update | Developmental | PFAS affect development in zebra fish | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced developmental effects
Liu et al. (2020c) | Lit Update | Other | PFAS effects on pancreatic and endocrine pluripotent cell differentiation | No, results do not influence draft judgments or provide key insights into key science issues, nor do they provide additional insights into potential mechanisms of PFHxS-induced effects.
Rericha et al. (2021) | Lit Update | Neurodevelopmental | PFAS effects on zebrafish behavior | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced neurodevelopmental effects
Xie et al. (2021) | Lit Update | Other | PFAS and POPs effects on 3T3-L1 adipogenesis | No, results do not influence draft judgments or provide key insights into key science issues, nor do they provide additional insights into potential mechanisms of PFHxS-induced effects.
Hallberg et al. (2021) | Lit Update | Female reproductive | PFHxS effects on bovine preimplantation in-vitro | No.; Results do not change draft judgments or provide additional insights into potential mechanisms of PFHxS-induced female reproductive effects
Shen et al. (2020) | Lit Update | Other | PFAS effects on lipid bilayer | No, results do not influence draft judgments or provide key insights into key science issues, nor do they provide additional insights into potential mechanisms of PFHxS-induced effects.
U.S. EPA (2019a) | Lit Update | Other | CompTox Dashboard | No, results do not influence draft judgments or provide key insights into key science issues, nor do they provide additional insights into potential mechanisms of PFHxS-induced effects.

No animal studies were identified in the April 2023 literature search.

1 A total of 186 studies were submitted by the State of New Jersey Department of Environmental Protection and the Natural Resources Defense Council (NRDC). There was a large amount of overlap between these studies and those already identified and screened for inclusion in the draft IRIS PFHxS assessment by EPA before April 2022. Those not already identified were screened using the PFHxS assessment PECO criteria. Table B-5 lists as “Commenter (on PFDA)” those studies meeting PECO criteria that were not identified before April 2022 and not identified through the routine EPA literature update in 2023.