# APPENDIX A SYSTEMATIC REVIEW PROTOCOL

A single systematic review protocol was used to guide the development of five, separate IRIS PFAS assessments (i.e., PFBA, PFHxA, PFHxS, PFNA, and PFDA). This “systematic review protocol for the PFAS IRIS assessments” was released for public comment and subsequently updated. The updated protocol and prior revisions can be found at the following location: http://cfpub.epa.gov/ncea/irisdrafts/recordisplay.cfm?deid=345065 (http://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=345065).