# ABBREVIATIONS AND ACRONYMS

ADHD: attention deficit hyperactivity disorder
AIC: Akaike’s information criterion
ALT: alanine aminotransferase
AST: aspartate aminotransferase
atm: atmosphere
ATSDR: Agency for Toxic Substances and Disease Registry
BMD: benchmark dose
BMDL: benchmark dose lower confidence limit
BMDS: Benchmark Dose Software
BMR: benchmark response
BUN: blood urea nitrogen
BW: body weight
CA: chromosomal aberration
CASRN: Chemical Abstracts Service registry number
CHO: Chinese hamster ovary (cell line cells)
CPHEA: Center for Public Health and Environmental Assessment
CL: confidence limit
CNS: central nervous system
CYP450: cytochrome P450
DAF: dosimetric adjustment factor
DDEF: data-derived extrapolation factor
DMSO: dimethylsulfoxide
DNA: deoxyribonucleic acid
EPA: Environmental Protection Agency
ER: extra risk
FDA: Food and Drug Administration
FEV_1_: forced expiratory volume of 1 second
GD: gestation day
GDH: glutamate dehydrogenase
GGT: γ-glutamyl transferase
GLP: good laboratory practices
GSH: glutathione
GST: glutathione-S-transferase
HBCD: hexabromocyclododecane
Hb/g-A: animal blood:gas partition coefficient
Hb/g-H: human blood:gas partition coefficient
HEC: human equivalent concentration
HED: human equivalent dose
HERO: Health and Environmental Research Online
i.p.: intraperitoneal
IRIS: Integrated Risk Information System
i.v.: intravenous
LC_50_: median lethal concentration
LD_50_: median lethal dose
LOAEL: lowest-observed-adverse-effect level
MN: micronuclei
MNPCE: micronucleated polychromatic erythrocyte
MOA: mode of action
MTD: maximum tolerated dose
NCI: National Cancer Institute
NOAEL: no-observed-adverse-effect level
NTP: National Toxicology Program
NZW: New Zealand White (rabbit breed)
ORD: Office of Research and Development
osRfD: organ-specific reference dose
PBPK: physiologically based pharmacokinetic
PFHxS: perfluorohexanesulfonic acid
PND: postnatal day
POD: point of departure
POD_[ADJ]_: duration-adjusted POD
QSAR: quantitative structure-activity relationship
RD: relative deviation
RfC: inhalation reference concentration
RfD: oral reference dose
RGDR: regional gas dose ratio
RNA: ribonucleic acid
SAR: structure activity relationship
SCE: sister chromatid exchange
SD: standard deviation
SDH: sorbitol dehydrogenase
SE: standard error
SEM: Systematic Evidence Map
SGOT: glutamic oxaloacetic transaminase, also known as AST
SGPT: glutamic pyruvic transaminase, also known as ALT
TSCATS: Toxic Substances Control Act Test Submissions
TWA: time-weighted average
UF: uncertainty factor
UF_A_: animal-to-human uncertainty factor
UF_D_: database deficiencies uncertainty factor
UF_H_: human variation uncertainty factor
UF_L_: LOAEL-to-NOAEL uncertainty factor
UF_S_: subchronic-to-chronic uncertainty factor
WOS: Web of Science