# Supplementary Materials

- ORD Staff Handbook for Developing IRIS Assessments (PDF)
- NATIONAL DEFENSE AUTHORIZATION ACT FOR FISCAL YEAR 2020 (PDF)