# REFERENCES

Abir, T; Rahman, B; D’Este, C; Farooq, A; Milton, AH. (2012). The association between chronic arsenic exposure and hypertension: A meta-analysis [Review]. J Toxicol 2012: 198793. 10.1155/2012/198793.22523484
Abuawad, A; Goldsmith, J; Herbstman, JB; Parvez, F; Islam, T; Loiacono, N; Graziano, JH; Navas-Acien, A; Gamble, M. Urine Dilution Correction Methods Utilizing Urine Creatinine or Specific Gravity in Arsenic Analyses: Comparisons to Blood and Water Arsenic in the FACT and FOX Studies in Bangladesh. Water. 10.3390/w14091477.
ADA (American Diabetes Association). (2004). Smoking and diabetes. Diabetes Care 27(Suppl. 1): s74–s75. 10.2337/diacare.27.2007.S74.14693932
Adams, JB; Audhya, T; Mcdonough-Means, S; Rubin, RA; Quig, D; Geis, E; Gehn, E; Loresto, M; Mitchell, J; Atwood, S; Barnhouse, S; Lee, W. (2013). Toxicological status of children with autism vs. neurotypical children and the association with autism severity. Biol Trace Elem Res 151: 171–180. 10.1007/s12011-012-9551-1.23192845
Adams, MA; Bolger, PM; Gunderson, EL. (1994). Dietary intake and hazards of arsenic. In WR Chappell; CO Abernathy; CC Richard (Eds.), Arsenic exposure and health (pp. 41–49). London: Northwood.
Adams, SV; Barrick, B; Christopher, EP; Shafer, MM; Song, X; Vilchis, H; Newcomb, PA; Ulery, A. (2015). Urinary heavy metals in Hispanics 40-85 years old in Doña Ana County, New Mexico. Arch Environ Occup Health 71: 1–9. 10.1080/19338244.2015.1129301.
Aelion, CM; Davis, HT; Lawson, AB; Cai, B; Mcdermott, S. (2012). Associations of estimated residential soil arsenic and lead concentrations and community-level environmental measures with mother-child health conditions in South Carolina. Health Place 18: 774–781. 10.1016/j.healthplace.2012.04.005.22579118
Ahmad, SA; Khatun, F; Sayed, MHS, U; Khan, MH; Aziz, MR; Hossain, MZ; Faruquee, MH. (2006). Electrocardiographic abnormalities among arsenic-exposed persons through groundwater in Bangladesh. J Health Popul Nutr 24: 221–227.17195563
Ahmad, SA; Sayed, MHS, U; Barua, S; Khan, MH; Faruquee, MH; Jalil, A; Hadi, SA; Talukder, HK. (2001). Arsenic in drinking water and pregnancy outcomes. Environ Health Perspect 109: 629–631. 10.1289/ehp.01109629.11445518
Ahmed, S; Khoda, SE; Rekha, RS; Gardner, RM; Ameer, SS; Moore, S; Ekström, E, -C; Vahter, M; Raqib, R. (2011). Arsenic-associated oxidative stress, inflammation, and immune disruption in human placenta and cord blood. Environ Health Perspect 119: 258–264. 10.1289/ehp.1002086.20940111
Allen, B; Shao, K; Hobbie, K; Mendez, W, Jr; Lee, JS; Cote, I; Druwe, I; Gift, J; Davis, JA. (2020a). Systematic dose-response of environmental epidemiologic studies: Dose and response pre-analysis. Environ Int 142: 105810. 10.1016/j.envint.2020.105810.32563010
Allen, B; Shao, K; Hobbie, K; Mendez, W, Jr; Lee, JS; Cote, I; Druwe, I; Gift, JS; Davis, JA. (2020b). Bayesian hierarchical dose-response meta-analysis of epidemiological studies: Modeling and target population prediction methods. Environ Int 145: 106111. 10.1016/j.envint.2020.106111.32971419
Almberg, KS; Turyk, ME; Jones, RM; Rankin, K; Freels, S; Graber, JM; Stayner, LT. (2017). Arsenic in drinking water and adverse birth outcomes in Ohio. Environ Res 157: 52–59. 10.1016/j.envres.2017.05.010.28521257
Ameer, SS; Engström, K; Harari, F; Concha, G; Vahter, M; Broberg, K. (2015). The effects of arsenic exposure on blood pressure and early risk markers of cardiovascular disease: Evidence for population differences. Environ Res 140: 32–36. 10.1016/j.envres.2015.03.010.25825128
Anderko, L; Braun, J, oe; Auinger, P. (2010). Contribution of Tobacco Smoke Exposure to Learning Disabilities. J Obstet Gynecol Neonatal Nurs 111–117. 10.1111/j.1552-6909.2009.01093.x.
APA (American Psychiatric Association). (2013). Diagnostic and statistical manual of mental disorders (5th ed.). Arlington, VA. 10.1176/appi.books.9780890425596.
Argos, M; Parvez, F; Rahman, M; Rakibuz-Zaman, M; Ahmed, A; Hore, SK; Islam, T; Chen, Y; Pierce, BL; Slavkovich, V; Olopade, C; Yunus, M; Baron, JA; Graziano, JH; Ahsan, H. (2014). Arsenic and lung disease mortality in Bangladeshi adults. Epidemiology 25: 536–543. 10.1097/EDE.0000000000000106.24802365
Ashley-Martin, J; Fisher, M; Belanger, P; Cirtiu, CM; Arbuckle, TE. (2022). Biomonitoring of inorganic arsenic species in pregnancy [Review]. J Expo Sci Environ Epidemiol. 10.1038/s41370-022-00457-2.
ATSDR (Agency for Toxic Substances and Disease Registry). (1996). Dynamometer study of off-cycle exhaust emissions, April 1996.
ATSDR (Agency for Toxic Substances and Disease Registry). (2000). Toxicological profile for arsenic (update) [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB2000108021.xhtml.
ATSDR (Agency for Toxic Substances and Disease Registry). (2007). Toxicological profile for arsenic (update) [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. http://www.atsdr.cdc.gov/toxprofiles/tp.asp?id=22&tid=3.
ATSDR (Agency for Toxic Substances and Disease Registry). (2016). Addendum to the toxicological profile for arsenic [ATSDR Tox Profile]. Atlanta, GA: Agency for Toxic Substances and Disease Registry, Division of Toxicology and Human Health Sciences. https://www.atsdr.cdc.gov/toxprofiles/Arsenic_addendum.pdf.
ATSDR (Agency for Toxic Substances and Disease Registry). (2022). Toxicological profile for mercury draft for public comment. Available online at https://www.atsdr.cdc.gov/toxprofiles/tp46.pdf.
Bailey, KA; Laine, J; Rager, JE; Sebastian, E; Olshan, A; Smeester, L; Drobná, Z; Stýblo, M; Rubio-Andrade, M; García-Vargas, G; Fry, RC. (2014). Prenatal arsenic exposure and shifts in the newborn proteome: Inter-individual differences in tumor necrosis factor (TNF)-responsive signaling. Toxicol Sci 139: 328–337. 10.1093/toxsci/kfu053.24675094
Bao, L; Shi, H. (2010). Arsenite induces endothelial cell permeability increase through a reactive oxygen species-Vascular endothelial growth factor pathway. Chem Res Toxicol 23: 1726–1734. 10.1021/tx100191t.20954712
Barchowsky, A; Dudek, EJ; Treadwell, MD; Wetterhahn, KE. (1996). Arsenic induces oxidant stress and NF-kappa B activation in cultured aortic endothelial cells. Free Radic Biol Med 21: 783–790. 10.1016/0891-5849(96)00174-8.8902524
Barchowsky, A; Klei, LR; Dudek, EJ; Swartz, HM; James, PE. (1999). Stimulation of reactive oxygen, but not reactive nitrogen species, in vascular endothelial cells exposed to low levels of arsenite. Free Radic Biol Med 27: 1405–1412. 10.1016/S0891-5849(99)00186-0.10641735
Baris, D; Waddell, R; Beane Freeman, LE; Schwenn, M; Colt, JS; Ayotte, JD; Ward, MH; Nuckols, J; Schned, A; Jackson, B; Clerkin, C; Rothman, N; Moore, LE; Taylor, A; Robinson, G; Hosain, GM; Armenti, KR; Mccoy, R; Samanic, C; Hoover, RN; Fraumeni, JF; Johnson, A; Karagas, MR; Silverman, DT. (2016). Elevated Bladder Cancer in Northern New England: The Role of Drinking Water and Arsenic. J Natl Cancer Inst 108: A3. 10.1093/jnci/djw099.
Barr, DB; Wilder, LC; Caudill, SP; Gonzalez, AJ; Needham, LL; Pirkle, JL. (2005). Urinary creatinine concentrations in the US population: Implications for urinary biologic monitoring measurements. Environ Health Perspect 113: 192–200. 10.1289/ehp.7337.15687057
Bates, MN; Rey, OA; Biggs, ML; Hopenhayn, C; Moore, LE; Kalman, D; Steinmaus, C; Smith, AH. (2004). Case-control study of bladder cancer and exposure to arsenic in Argentina. Am J Epidemiol 159: 381–389. 10.1093/aje/kwh054.14769642
Bates, MN; Smith, AH; Cantor, KP. (1995). Case-control study of bladder cancer and arsenic in drinking water. 141: 523–530.
Bermudez, L; Garcia-Vicent, C; Lopez, J; Isabel Torro, M; Lurbe, E. (2015). Assessment of ten trace elements in umbilical cord blood and maternal blood: Association with birth weight. J Transl Med 13: 291. 10.1186/s12967-015-0654-2.26346609
Bernstam, L; Lan, CH; Lee, J; Nriagu, JO. (2002). Effects of arsenic on human keratinocytes: Morphological, physiological, and precursor incorporation studies. Environ Res 89: 220–235. 10.1006/enrs.2002.4367.12176006
Bloom, MS; Buck Louis, GM; Sundaram, R; Maisog, JM; Steuerwald, AJ; Parsons, PJ. (2015). Birth outcomes and background exposures to select elements, the Longitudinal Investigation of Fertility and the Environment (LIFE). Environ Res 138: 118–129. 10.1016/j.envres.2015.01.008.25707016
Bloom, MS; Neamtiu, IA; Surdu, S; Pop, C; Anastasiu, D; Appleton, AA; Fitzgerald, EF; Gurzau, ES. (2016). Low level arsenic contaminated water consumption and birth outcomes in Romania-An exploratory study. Reprod Toxicol 59: 8–16. 10.1016/j.reprotox.2015.10.012.26518419
Bloom, MS; Neamtiu, IA; Surdu, S; Pop, C; Lupsa, IR; Anastasiu, D; Fitzgerald, EF; Gurzau, ES. (2014). Consumption of low-moderate level arsenic contaminated water does not increase spontaneous pregnancy loss: a case control study. Environ Health 13: 81. 10.1186/1476-069X-13-81.25311704
Bräuner, EV; Nordsborg, RB; Andersen, ZJ; Tjønneland, A; Loft, S; Raaschou-Nielsen, O. (2014). Long-term exposure to low-level arsenic in drinking water and diabetes incidence: A prospective study of the diet, cancer and health cohort. Environ Health Perspect 122: 1059–1065. 10.1289/ehp.1408198.24927198
Budavari, S, O’Neil, M.,.J. Smith, A., Heckelman, P.,.E. (1989). The Merck index: An encyclopedia of chemicals, drugs, and biologicals. In SONMJSAHPE Budavari (Ed.), (11th ed., pp. 864). Rahway, NJ: Merck Research Laboratories Division of Merck & Co., Inc. https://www.amazon.com/Merck-Index-Eleventh-Susan-Budavari/dp/B0036FBD2K.
Bulka, CM; Scannell Bryan, M; Lombard, MA; Bartell, SM; Jones, DK; Bradley, PM; Vieira, VM; Silverman, DT; Focazio, M; Toccalino, PL; Daniel, J; Backer, LC; Ayotte, JD; Gribble, MO; Argos, M. (2022). Arsenic in private well water and birth outcomes in the United States. Environ Int 163: 107176. 10.1016/j.envint.2022.107176.35349912
Bunderson, M; Brooks, DM; Walker, DL; Rosenfeld, ME; Coffin, JD; Beall, HD. (2004). Arsenic exposure exacerbates atherosclerotic plaque formation and increases nitrotyrosine and leukotriene biosynthesis. Toxicol Appl Pharmacol 201: 32–39. 10.1016/j.taap.2004.04.008.15519606
Burgess, JL; Kurzius-Spencer, M; O’Rourke, MK; Littau, SR; Roberge, J; Meza-Montenegro, MM; Gutiérrez-Millán, LE; Harris, RB. (2013). Environmental arsenic exposure and serum matrix metalloproteinase-9. J Expo Sci Environ Epidemiol 23: 163–169. 10.1038/jes.2012.107.23232971
Butler, EE; Karagas, MR; Demidenko, E; Bellinger, DC; Korrick, SA. (2023). In utero arsenic exposure and early childhood motor development in the New Hampshire Birth Cohort Study. Front Epidemiol 3: 1139337. 10.3389/fepid.2023.1139337.38455900
Calderón, J; Navarro, ME; Jimenez-Capdeville, ME; Santos-Diaz, MA; Golden, A; Rodriguez-Leyva, I; Borja-Aburto, V; Díaz-Barriga, F. (2001). Exposure to arsenic and lead and neuropsychological development in Mexican children. Environ Res 85: 69–76. 10.1006/enrs.2000.4106.11161656
Carignan, CC; Cottingham, KL; Jackson, BP; Farzan, SF; Gandolfi, AJ; Punshon, T; Folt, CL; Karagas, MR. (2015). Estimated Exposure to Arsenic in Breastfed and Formula-Fed Infants in a United States Cohort. Environ Health Perspect 123: 500–506. 10.1289/ehp.1408789.25707031
Carnicer, R; Crabtree, MJ; Sivakumaran, V; Casadei, B; Kass, DA. (2013). Nitric Oxide Synthases in Heart Failure [Review]. Antioxid Redox Signal 18: 1078–1099. 10.1089/ars.2012.4824.22871241
Chang, CH; Liu, CS; Liu, HJ; Huang, CP; Huang, CY; Hsu, HT; Liou, SH; Chung, CJ. (2016). Association between levels of urinary heavy metals and increased risk of urothelial carcinoma. Int J Urol 23: 233–239. 10.1111/iju.13024.26663353
Chen, C, -J; Chiou, H, -Y; Chiang, M, -H; Lin, L, -J; Tai, T, -Y. (1996). Dose-response relationship between ischemic heart disease mortality and long-term arsenic exposure. Arterioscler Thromb Vasc Biol 16: 504–510. 10.1161/01.ATV.16.4.504.8624771
Chen, C, -J; Hsueh, Y, -M; Lai, M, -S; Shyu, M, -P; Chen, S, -Y; Wu, M, -M; Kuo, T, -L; Tai, T, -Y. (1995). Increased prevalence of hypertension and long-term arsenic exposure. Hypertension 25: 53–60. 10.1161/01.HYP.25.1.53.7843753
Chen, C, -J; Wu, M, -M; Lee, S, -S; Wang, J, -D; Cheng, S, -H; Wu, H, -Y. (1988). Atherogenicity and carcinogenicity of high-arsenic artesian well water. Multiple risk factors and related malignant neoplasms of blackfoot disease. 8: 452–460. 10.1161/01.ATV.8.5.452.
Chen, C, -L; Hsu, L, -I; Chiou, H, -Y; Hsueh, Y, -M; Chen, S, -Y; Wu, M, -M; Chen, C, -J; Group, ftBDS. (2004). Ingested arsenic, cigarette smoking, and lung cancer risk: A follow-up study in arseniasis-endemic areas in Taiwan. JAMA 292: 2984–2990. 10.1001/jama.292.24.2984.15613666
Chen, CL; Chiou, HY; Hsu, LI; Hsueh, YM; Wu, MM; Chen, CJ. (2010a). Ingested arsenic, characteristics of well water consumption and risk of different histological types of lung cancer in northeastern Taiwan. Environ Res 110: 455–462. 10.1016/j.envres.2009.08.010.19735913
Chen, CL; Chiou, HY; Hsu, LI; Hsueh, YM; Wu, MM; Wang, YH; Chen, CJ. (2010b). Arsenic in drinking water and risk of urinary tract cancer: A follow-up study from northeastern Taiwan. Cancer Epidemiol Biomarkers Prev 19: 101–110. 10.1158/1055-9965.EPI-09-0333.20056628
Chen, H; Zhang, HL; Wang, X; Wu, Y; Zhang, YQ; Chen, SL; Zhang, WX; Sun, XJ; Zheng, TZ; Xia, W; Xu, SQ; Li, YY. (2023). Prenatal arsenic exposure, arsenic metabolism and neurocognitive development of 2-year-old children in low-arsenic areas. Environ Int 174: 107918. 10.1016/j.envint.2023.107918.37043832
Chen, J, -W; Wang, S, -L; Wang, Y, -H; Sun, C, -W; Huang, Y, -L; Chen, C, -J; Li, W, -F. (2012a). Arsenic methylation, GSTO1 polymorphisms, and metabolic syndrome in an arseniasis endemic area of southwestern Taiwan. Chemosphere 88: 432–438. 10.1016/j.chemosphere.2012.02.059.22440634
Chen, J; Stinnett, A. (2008). Critical role of the NADPH oxidase subunit p47phox on vascular TLR expression and neointimal lesion formation in high-fat diet-induced obesity. Lab Invest 88: 1316–1328. 10.1038/labinvest.2008.92.18779779
Chen, JW; Chen, HY; Li, WF; Liou, SH; Chen, CJ; Wu, JH; Wang, SL. (2011a). The association between total urinary arsenic concentration and renal dysfunction in a community-based population from central Taiwan. Chemosphere 84: 17–24. 10.1016/j.chemosphere.2011.02.091.21458841
Chen, Q; Wang, Q; Zhu, J; Xiao, Q; Zhang, L. (2017). Reactive oxygen species: Key regulators in vascular health and diseases. Br J Pharmacol 175: 1279–1292. 10.1111/bph.13828.28430357
Chen, R; Clifford, A; Lang, L; Anstey, KJ. (2013a). Is exposure to secondhand smoke associated with cognitive parameters of children and adolescents?-a systematic literature review [Review]. Ann Epidemiol 23: 652–661. 10.1016/j.annepidem.2013.07.001.23969303
Chen, SC; Chen, CC; Kuo, CY; Huang, CH; Lin, CH; Lu, ZY; Chen, YY; Lee, HS; Wong, RH. (2012b). Elevated risk of hypertension induced by arsenic exposure in Taiwanese rural residents: Possible effects of manganese superoxide dismutase (MnSOD) and 8-oxoguanine DNA glycosylase (OGG1) genes. Arch Toxicol 86: 869–878. 10.1007/s00204-011-0797-8.22193621
Chen, SC; Chen, WC. (2008). Vascular leakage induced by exposure to arsenic via increased production of NO, hydroxyl radical and peroxynitrite. Microvasc Res 75: 373–380. 10.1016/j.mvr.2007.12.004.18243249
Chen, Y, -C; Su, H, -JJ; Guo, Y, -LL; Hsueh, Y, -M; Smith, TJ; Ryan, LM; Lee, M, -S; Christiani, DC. (2003). Arsenic methylation and bladder cancer risk in Taiwan. Cancer Causes Control 14: 303–310. 10.1023/A:1023905900171.12846360
Chen, Y; Ahsan, H; Slavkovich, V; Peltier, GL; Gluskin, RT; Parvez, F; Liu, X; Graziano, JH. (2010c). No association between arsenic exposure from drinking water and diabetes mellitus: A cross-sectional study in Bangladesh. Environ Health Perspect 118: 1299–1305. 10.1289/ehp.0901559.20813654
Chen, Y; Factor-Litvak, P; Howe, GR; Graziano, JH; Brandt-Rauf, P; Parvez, F; van Geen, A; Ahsan, H. (2007). Arsenic exposure from drinking water, dietary intakes of B vitamins and folate, and risk of high blood pressure in Bangladesh: A population-based, cross-sectional study. Am J Epidemiol 165: 541–552. 10.1093/aje/kwk037.17164464
Chen, Y; Graziano, JH; Parvez, F; Liu, M; Slavkovich, V; Kalra, T; Argos, M; Islam, T; Ahmed, A; Rakibuz-Zaman, M; Hasan, R; Sarwar, G; Levy, D; van Geen, A; Ahsan, H. (2011b). Arsenic exposure from drinking water and mortality from cardiovascular disease in Bangladesh: Prospective cohort study. Br Med J 342: d2431. 10.1136/bmj.d2431.21546419
Chen, Y; Hakim, ME; Parvez, F; Islam, T; Rahman, AM; Ahsan, H. (2006). Arsenic exposure from drinking-water and carotid artery intima-medial thickness in healthy young adults in Bangladesh. J Health Popul Nutr 24: 253–257.17195567
Chen, Y; Wu, F; Graziano, JH; Parvez, F; Liu, M; Paul, RR; Shaheen, I; Sarwar, G; Ahmed, A; Islam, T; Slavkovich, V; Rundek, T; Demmer, RT; Desvarieux, M; Ahsan, H. (2013b). Arsenic exposure from drinking water, arsenic methylation capacity, and carotid intima-media thickness in Bangladesh. Am J Epidemiol 178: 372–381. 10.1093/aje/kwt001.23788675
Chen, Y; Wu, F; Liu, M; Parvez, F; Slavkovich, V; Eunus, M; Ahmed, A; Segers, S; Argos, M; Islam, T; Rakibuz-Zaman, M; Hasan, R; Sarwar, G; Levy, D; Graziano, J; Ahsan, H. (2013c). A prospective study of arsenic exposure, arsenic methylation capacity, and risk of cardiovascular disease in Bangladesh. Environ Health Perspect 121: 832–838. 10.1289/ehp.1205797.23665672
Chen, Y; Wu, F; Parvez, F; Ahmed, A; Eunus, M; McClintock, TR; Patwary, TI; Islam, T; Ghosal, AK; Islam, S; Hasan, R; Levy, D; Sarwar, G; Slavkovich, V; van Geen, A; Graziano, JH; Ahsan, H. (2013d). Arsenic exposure from drinking water and QT-interval prolongation: Results from the Health Effects of Arsenic Longitudinal Study. Environ Health Perspect 121: 427–432. 10.1289/ehp.1205197.23384555
Cherry, N; Shaik, K; McDonald, C; Chowdhury, Z. (2010). Manganese, arsenic, and infant mortality in Bangladesh: An ecological analysis. Arch Environ Occup Health 65: 148–153. 10.1080/19338240903390362.20705575
Cherry, N; Shaikh, K; McDonald, C; Chowdhury, Z. (2008). Stillbirth in rural Bangladesh: Arsenic exposure and other etiological factors: A report from Gonoshasthaya Kendra. Bull World Health Organ 86: 172–177. 10.2471/blt.07.043083.18368203
Chiou, H, -Y; Chiou, S, -T; Hsu, Y, -H; Chou, Y, -L; Tseng, C, -H; Wei, M, -L; Chen, C, -J. (2001a). Incidence of transitional cell carcinoma and arsenic in drinking water: A follow-up study of 8,102 residents in an arseniasis-endemic area in northeastern Taiwan. Am J Epidemiol 153: 411–418. 10.1093/aje/153.5.411.11226969
Chiou, H, -Y; Huang, W, -I; Su, C, -L; Chang, S, -F; Hsu, Y, -H; Chen, C, -J. (1997). Dose-response relationship between prevalence of cerebrovascular disease and ingested inorganic arsenic. Stroke 28: 1717–1723. 10.1161/01.STR.28.9.1717.9303014
Chiou, HY; Hsueh, YM; Liaw, KF; Horng, SF; Chiang, MH; Pu, YS; Lin, JSN; Huang, CH; Chen, CJ. (1995). Incidence of internal cancers and ingested inorganic arsenic: A seven-year follow-up study in Taiwan. Cancer Res 55: 1296–1300.7882325
Chiou, HY; Wang, IH; Hsueh, YM; Chiou, ST; Chou, YL; Teh, HW; Chen, CJ. (2001b). Arsenic exposure, null genotypes of glutathione S-transferase M1, T1 and P1, and risk of carotid atherosclerosis among residents in the Lanyang Basin of Taiwan. In WR Chappell; CO Abernathy; RL Calderon (Eds.), Arsenic Exposure and Health Effects IV (pp. 207–219). Amsterdam, The Netherlands: Elsevier Science.
Chiou, J, -M; Wang, S, -L; Chen, C, -J; Deng, C, -R; Lin, W; Tai, T, -Y. (2005). Arsenic ingestion and increased microvascular disease risk: Observations from the south-western arseniasis-endemic area in Taiwan. Int J Epidemiol 34: 936–943. 10.1093/ije/dyi108.15911542
Chung, C, -J; Huang, C, -Y; Pu, Y, -S; Shiue, H, -S; Su, C, -T; Hsueh, Y, -M. (2013a). The effect of cigarette smoke and arsenic exposure on urothelial carcinoma risk is modified by glutathione S-transferase M1 gene null genotype. Toxicol Appl Pharmacol 266: 254–259. 10.1016/j.taap.2012.11.005.23159782
Chung, C, -J; Huang, Y, -L; Huang, Y, -K; Wu, M, -M; Chen, S, -Y; Hsueh, Y, -M; Chen, C, -J. (2013b). Urinary arsenic profiles and the risks of cancer mortality: A population-based 20-year follow-up study in arseniasis-endemic areas in Taiwan. Environ Res 122: 25–30. 10.1016/j.envres.2012.11.007.23276485
Chung, C, -J; Pu, Y, -S; Chen, Y, -T; Su, C, -T; Wu, C, -C; Shiue, H, -S; Huang, C, -Y; Hsueh, Y, -M. (2011a). Protective effects of plasma alpha-tocopherols on the risk of inorganic arsenic-related urothelial carcinoma. Sci Total Environ 409: 1039–1045. 10.1016/j.scitotenv.2010.11.037.21227482
Chung, CJ; Pu, YS; Su, CT; Huang, CY; Hsueh, YM. (2011b). Gene polymorphisms of glutathione S-transferase omega 1 and 2, urinary arsenic methylation profile and urothelial carcinoma. Sci Total Environ 409: 465–470. 10.1016/j.scitotenv.2010.10.053.21094982
Claffey, KP; Abrams, K; Shih, SC; Brown, LF; Mullen, A; Keough, M. (2001). Fibroblast growth factor 2 activation of stromal cell vascular endothelial growth factor expression and angiogenesis. Lab Invest 81: 61–75. 10.1038/labinvest.3780212.11204275
Clark, J; Bommarito, P; Stýblo, M; Rubio-Andrade, M; García-Vargas, GG; Gamble, MV; Fry, RC. (2022). Maternal serum concentrations of one-carbon metabolism factors modify the association between biomarkers of arsenic methylation efficiency and birth weight. Environ Health 21: 68. 10.1186/s12940-022-00875-7.35836250
Claus Henn, B; Ettinger, AS; Hopkins, MR; Jim, R; Amarasiriwardena, C; Christiani, DC; Coull, BA; Bellinger, DC; Wright, RO. (2016). Prenatal Arsenic Exposure and Birth Outcomes among a Population Residing near a Mining-Related Superfund Site. Environ Health Perspect 124: 1308–1315. 10.1289/ehp.1510070.26859631
Clewell, HJ; Thomas, RS; Gentry, PR; Crump, KS; Kenyon, EM; El-Masri, HA; Yager, JW. (2007). Research toward the development of a biologically based dose response assessment for inorganic arsenic carcinogenicity: A progress report. Toxicol Appl Pharmacol 222: 388–398. 10.1016/j.taap.2007.03.021.17499324
Coffin, J; Greenwell, RJ; Brooks, DM; Calderon, LG; Beall, HD. (2006). Vascular dysmorphogenesis causes placental insufficiency and miscarraige in arsenic exposed mice [Abstract]. Toxicol Sci 90: 74.
Cohen, SM; Arnold, LL; Eldan, M; Lewis, AS; Beck, BD. (2006). Methylated arsenicals: The implications of metabolism and carcinogenicity studies in rodents to human risk assessment [Review]. Crit Rev Toxicol 36: 99–133. 10.1080/10408440500534230.16736939
Concha, G; Vogler, G; Lezcano, D; Nermell, B; Vahter, M. (1998). Exposure to inorganic arsenic metabolites during early human development. Toxicol Sci 44: 185–190. 10.1093/toxsci/44.2.185.9742656
Coronado-González, JA; Del Razo, LM; García-Vargas, G; Sanmiguel-Salazar, F; Escobedo-de la Peña, J. (2007). Inorganic arsenic exposure and type 2 diabetes mellitus in Mexico. Environ Res 104: 383–389. 10.1016/j.envres.2007.03.004.17475235
Corrêa, ML; Soares, PS; da Silva, BGC; Wehrmeister, F; Horta, BL; Menezes, AMB. (2021). Maternal smoking during pregnancy and intelligence quotient in offspring: A systematic review and meta-analysis [Review]. Neurotoxicology 85: 99–114. 10.1016/j.neuro.2021.05.007.34004235
Currier, JM; Ishida, MC; González-Horta, C; Sánchez-Ramírez, B; Ballinas-Casarrubias, L; Gutiérrez-Torres, DS; Cerón, RH; Morales, DV; Terrazas, FA; Del Razo, LM; García-Vargas, GG; Saunders, RJ; Drobná, Z; Fry, RC; Matoušek, T; Buse, JB; Mendez, MA; Loomis, D; Stýblo, M. (2014). Associations between arsenic species in exfoliated urothelial cells and prevalence of diabetes among residents of Chihuahua, Mexico. Environ Health Perspect 122: 1088–1094. 10.1289/ehp.1307756.25000461
D’Ippoliti, D; Santelli, E; De Sario, M; Scortichini, M; Davoli, M; Michelozzi, P. (2015). Arsenic in Drinking Water and Mortality for Cancer and Chronic Diseases in Central Italy, 1990-2010. PLoS ONE 10: e0138182. 10.1371/journal.pone.0138182.26383851
Dai, YM; Lu, HY; Zhang, JM; Ding, JY; Wang, Z; Zhang, BY; Qi, XJ; Chang, XL; Wu, CH; Zhou, ZJ. (2023). Sex-specific associations of maternal and childhood urinary arsenic levels with emotional problems among 6-year-age children: Evidence from a longitudinal cohort study in China. Ecotoxicol Environ Saf 267: 115658. 10.1016/j.ecoenv.2023.115658.37925797
Daniali, SS; Yazdi, M; Heidari-Beni, M; Taheri, E; Zarean, E; Goli, P; Kelishadi, R. (2023). Birth size outcomes in relation to maternal blood levels of some essential and toxic elements. Biol Trace Elem Res 201: 4–13. 10.1007/s12011-022-03121-w.35298828
Das, N; Paul, S; Chatterjee, D; Banerjee, N; Majumder, NS; Sarma, N; Sau, TJ; Basu, S; Banerjee, S; Majumder, P; Bandyopadhyay, AK; States, JC; Giri, AK. (2012). Arsenic exposure through drinking water increases the risk of liver and cardiovascular diseases in the population of West Bengal, India. BMC Public Health 12: 639. 10.1186/1471-2458-12-639.22883023
Dauphiné, DC; Smith, AH; Yuan, Y; Balmes, JR; Bates, MN; Steinmaus, C. (2013). Case-control study of arsenic in drinking water and lung cancer in California and Nevada. Int J Environ Res Public Health 10: 3310–3324. 10.3390/ijerph10083310.23917816
Davis, MA; Higgins, J; Li, Z; Gilbert-Diamond, D; Baker, ER; Das, A; Karagas, MR. (2015). Preliminary analysis of in utero low-level arsenic exposure and fetal growth using biometric measurements extracted from fetal ultrasound reports. Environ Health 14: 12. 10.1186/1476-069X-14-12.25971349
De Vizcaya-Ruiz, A; Barbier, O; Ruiz-Ramos, R; Cebrian, ME. (2009). Biomarkers of oxidative stress and damage in human populations exposed to arsenic [Review]. Mutat Res Genet Toxicol Environ Mutagen 674: 85–92. 10.1016/j.mrgentox.2008.09.020.
Del Razo, LM; García-Vargas, GG; Valenzuela, OL; Castellanos, EH; Sánchez-Peña, LC; Currier, JM; Drobná, Z; Loomis, D; Stýblo, M. (2011). Exposure to arsenic in drinking water is associated with increased prevalence of diabetes: A cross-sectional study in the Zimapán and Lagunera regions in Mexico. Environ Health 10: 73. 10.1186/1476-069X-10-73.21864395
Desai, G; Barg, G; Queirolo, EI; Vahter, M; Peregalli, F; Mañay, N; Kordas, K. (2018). A cross-sectional study of general cognitive abilities among Uruguayan school children with low-level arsenic exposure, potential effect modification by methylation capacity and dietary folate. Environ Res 164: 124–131. 10.1016/j.envres.2018.02.021.29486343
Desai, G; Barg, G; Vahter, M; Queirolo, EI; Peregalli, F; Mañay, N; Millen, AE; Yu, J; Browne, RW; Kordas, K. (2020a). Low level arsenic exposure, B-vitamins, and achievement among Uruguayan school children. Int J Hyg Environ Health 223: 124–131. 10.1016/j.ijheh.2019.09.011.31588016
Desai, G; Barg, G; Vahter, M; Queirolo, EI; Peregalli, F; Mañay, N; Millen, AE; Yu, J; Kordas, K. (2020b). Executive functions in school children from Montevideo, Uruguay and their associations with concurrent low-level arsenic exposure. Environ Int 142: 105883. 10.1016/j.envint.2020.105883.32599352
DeSimone, LA; McMahon, PB; Rosen, MR. (2015). The quality of our nation’s waters: water quality in principal aquifers of the United States, 1991–2010. DeSimone, LA; McMahon, PB; Rosen, MR. https://pubs.usgs.gov/circ/1360/.
Díaz-Villaseñor, A; Burns, AL; Hiriart, M; Cebrián, ME; Ostrosky-Wegman, P. (2007). Arsenic-induced alteration in the expression of genes related to type 2 diabetes mellitus [Review]. Toxicol Appl Pharmacol 225: 123–133. 10.1016/j.taap.2007.08.019.17936320
Díaz-Villaseñor, A; Cruz, L; Cebrián, A; Hernández-Ramírez, RU; Hiriart, M; García-Vargas, G; Bassol, S; Sordo, M; Gandolfi, AJ; Klimecki, WT; López-Carillo, L; Cebrián, ME; Ostrosky-Wegman, P. (2013). Arsenic exposure and calpain-10 polymorphisms impair the function of pancreatic beta-cells in humans: A pilot study of risk factors for T2DM. PLoS ONE 8: e51642. 10.1371/journal.pone.0051642.23349674
Divya, SP; Pratheeshkumar, P; Son, YO; Roy, RV; Hitron, JA; Kim, D; Dai, J; Wang, L; Asha, P; Huang, B; Xu, M; Luo, J; Zhang, Z. (2015). Arsenic induces insulin resistance in mouse adipocytes and myotubes via oxidative stress regulated mitochondrial Sirt3-FOXO3a signaling pathway. Toxicol Sci 146: 290–300. 10.1093/toxsci/kfv089.25979314
Dong, C; Taylor, MP; Kristensen, LJ; Zahran, S. (2015). Environmental contamination in an Australian mining community and potential influences on early childhood health and behavioural outcomes. Environ Pollut 207: 345–356. 10.1016/j.envpol.2015.09.037.26448503
Drobná, Z; Del Razo, LM; García-Vargas, GG; Sánchez-Peña, LC; Barrera-Hernández, A; Stýblo, M; Loomis, D. (2013). Environmental exposure to arsenic, AS3MT polymorphism and prevalence of diabetes in Mexico. J Expo Sci Environ Epidemiol 23: 151–155. 10.1038/jes.2012.103.23093101
Drobna, Z; Jaspers, I; Thomas, DJ; Styblo, M. (2003). Differential activation of AP-1 in human bladder epithelial cells by inorganic and methylated arsenicals. FASEB J 17: 67–69. 10.1096/fj.02-0287fje.12475910
Drobná, Z; Walton, FS; Harmon, AW; Thomas, DJ; Stýblo, M. (2010). Interspecies differences in metabolism of arsenic by cultured primary hepatocytes. Toxicol Appl Pharmacol 245: 47–56. 10.1016/j.taap.2010.01.015.20138079
Dzierlenga, M, .W.; Crawford, L, .; Longnecker, M, .P. (2020). Birth weight and perfluorooctane sulfonic acid: a random-effects meta-regression analysis. Environmental Epidemiology 4: e095. 10.1097/EE9.0000000000000095.33778349
Eblin, KE; Bredfeldt, TG; Buffington, S; Gandolfi, AJ. (2007). Mitogenic signal transduction caused by monomethylarsonous acid in human bladder cells: Role in arsenic-induced carcinogenesis. Toxicol Sci 95: 321–330. 10.1093/toxsci/kfl160.17093206
Eblin, KE; Jensen, TJ; Wnek, SM; Buffington, SE; Futscher, BW; Gandolfi, AJ. (2009). Reactive oxygen species regulate properties of transformation in UROtsa cells exposed to monomethylarsonous acid by modulating MAPK signaling. Toxicology 255: 107–114. 10.1016/j.tox.2008.10.007.19014992
EFSA (European Food Safety Authority). (2009). Scientific opinion on arsenic in food. 7: 1351. 10.2903/j.efsa.2009.1351.
Egwunye, J; Cardoso, BR; Braat, S; Tran, H; Hanieh, S; Hare, D; Duan, AX; Doronila, A; Tran, T; Tuan, T; Fisher, J; Biggs, BA. (2022). The role of fingernail selenium in the association between arsenic, lead and mercury and child development in rural Vietnam: A cross-sectional analysis. Br J Nutr. 10.1017/S0007114522001374.
El-Masri, HA; Hong, T; Henning, C; Mendez, W; Hudgens, EE; Thomas, DJ; Lee, JS. (2018a). Erratum: “Evaluation of a physiologically based pharmacokinetic (PBPK) model for inorganic arsenic exposure using data from two diverse human populations” [Erratum]. Environ Health Perspect 126: 99002. 10.1289/EHP4370.30392381
El-Masri, HA; Hong, T; Henning, C; Mendez, W; Hudgens, EE; Thomas, DJ; Lee, JS. (2018b). Evaluation of a Physiologically Based Pharmacokinetic (PBPK) Model for Inorganic Arsenic Exposure Using Data from Two Diverse Human Populations. Environ Health Perspect 126: 077004. 10.1289/EHP3096.30024383
El-Masri, HA; Kenyon, EM. (2008). Development of a human physiologically based pharmacokinetic (PBPK) model for inorganic arsenic and its mono- and di-methylated metabolites. J Pharmacokinet Pharmacodyn 35: 31–68. 10.1007/s10928-007-9075-z.17943421
Engström, KS; Hossain, MB; Lauss, M; Ahmed, S; Raqib, R; Vahter, M; Broberg, K. (2013). Efficient arsenic metabolism-The AS3MT haplotype is associated with DNA methylation and expression of multiple genes around AS3MT. PLoS ONE 8: e53732. 10.1371/journal.pone.0053732.23341986
Escudero-Lourdes, C; Wu, T; Camarillo, JM; Gandolfi, AJ. (2012). Interleukin-8 (IL-8) over-production and autocrine cell activation are key factors in monomethylarsonous acid [MMA(III)]-induced malignant transformation of urothelial cells. Toxicol Appl Pharmacol 258: 10–18. 10.1016/j.taap.2011.10.002.22015448
Esper, RJ; Noradaby, RA; Vilariño, JO; Paragano, A; Cacharrón, JL; Machado, RA. (2006). Endothelial dysfunction: A comprehensive appraisal. Cardiovasc Diabetol 5. 10.1186/1475-2840-5-4.
Ettinger, AS; Zota, AR; Amarasiriwardena, CJ; Hopkins, MR; Schwartz, J; Hu, H; Wright, RO. (2009). Maternal arsenic exposure and impaired glucose tolerance during pregnancy. Environ Health Perspect 117: 1059–1064. 10.1289/ehp0800533.19654913
Fängström, B; Moore, S; Nermell, B; Kuenstl, L; Goessler, W; Grandér, M; Kabir, I; Palm, B; Arifeen, SE; Vahter, M. (2008). Breast-feeding protects against arsenic exposure in Bangladeshi infants. Environ Health Perspect 116: 963–969. 10.1289/ehp.11094.18629322
Fano-Sizgorich, D; Vásquez-Velásquez, C; Yucra, S; Vásquez, V; Tokeshi, P; Aguilar, J; Ramírez-Atencio, C; Barr, DB; Gonzales, GF. (2021). Total urinary arsenic and inorganic arsenic concentrations and birth outcomes in pregnant women of Tacna, Peru: A cross-sectional study. Exposure and Health 13: 133–140. 10.1007/s12403-020-00377-2.33575507
Farzan, SF; Chen, Y, u; Rees, J. R.; Zens, MS; Karagas, MR. (2015a). Risk of death from cardiovascular disease associated with low-level arsenic exposure among long-term smokers in a US population-based study. Toxicol Appl Pharmacol 287: 93–97. 10.1016/j.taap.2015.05.013.26048586
Farzan, SF; Chen, Y; Wu, F; Jiang, J; Liu, M; Baker, E; Korrick, SA; Karagas, MR. (2015b). Blood pressure changes in relation to arsenic exposure in a U.S. pregnancy cohort. Environ Health Perspect 123: 999–1006. 10.1289/ehp.1408472.25793356
Farzan, SF; Gossai, A; Chen, Y; Chasan-Taber, L; Baker, E; Karagas, M. (2016). Maternal arsenic exposure and gestational diabetes and glucose intolerance in the New Hampshire birth cohort study. Environ Health 15: 106. 10.1186/s12940-016-0194-0.27825389
Farzan, SF; Karagas, MR; Chen, Y. (2013a). In utero and early life arsenic exposure in relation to long-term health and disease [Review]. Toxicol Appl Pharmacol 272: 384–390. 10.1016/j.taap.2013.06.030.23859881
Farzan, SF; Karagas, MR; Jiang, J; Wu, F; Liu, M; Newman, JD; Jasmine, F; Kibriya, MG; Paul-Brutus, R; Parvez, F; Argos, M; Bryan, MS; Eunus, M; Ahmed, A; Islam, T; Rakibuz-Zaman, M; Hasan, R; Sarwar, G; Slavkovich, V; Graziano, J; Ahsan, H; Chen, Y. (2015c). Gene-arsenic interaction in longitudinal changes of blood pressure: Findings from the Health Effects of Arsenic Longitudinal Study (HEALS) in Bangladesh. Toxicol Appl Pharmacol 288: 95–105. 10.1016/j.taap.2015.07.017.26220686
Farzan, SF; Korrick, S; Li, Z; Enelow, R; Gandolfi, AJ; Madan, J; Nadeau, K; Karagas, MR. (2013b). In utero arsenic exposure and infant infection in a United States cohort: A prospective study. Environ Res 126: 24–30. 10.1016/j.envres.2013.05.001.23769261
FDA (U.S. Food and Drug Administration). (2005). Beverages: bottled water. Final rule. Fed Reg 70: 33694–33701.
FDA (U.S. Food and Drug Administration). (2020). Inorganic arsenic in rice cereals for infants: Action level guidance for industry. College Park, MD.
FDA, US. (2013). A quantitative assessment of inorganic arsenic in apple juice. College Park, MD: U.S. Food and Drug Administration, Chemical Hazards Assessment Team, Center for Food Safety and Applied Nutrition. http://www.fda.gov/downloads/Food/FoodScienceResearch/RiskSafetyAssessment/UCM360016.pdf.
FDA, US. (2016). Arsenic in Rice and Rice Products. Risk Assessment Report. Center for Food Safety and Applied Nutrition, Food and Drug Administration, U.S. Department of Health and Human Services. https://www.fda.gov/downloads/Food/FoodScienceResearch/RiskSafetyAssessment/UCM486543.pdf.
Fei, DL; Koestler, DC; Li, Z; Giambelli, C; Sanchez-Mejias, A; Gosse, JA; Marsit, CJ; Karagas, MR; Robbins, DJ. (2013). Association between in utero arsenic exposure, placental gene expression, and infant birth weight: A US birth cohort study. Environ Health 12: 58. 10.1186/1476-069X-12-58.23866971
Feng, W; Cui, XQ; Liu, B; Liu, CY; Xiao, Y; Lu, W; Guo, H; He, MA; Zhang, XM; Yuan, J; Chen, WH; Wu, TC. (2015). Association of urinary metal profiles with altered glucose levels and diabetes risk: A population-based study in China. PLoS ONE 10: e0123742. 10.1371/journal.pone.0123742.25874871
Feng, W; He, X; Chen, M; Deng, S; Qiu, G; Li, X; Liu, C; Li, J; Deng, Q; Huang, S; Wang, T; Dai, X; Yang, B; Yuan, J; He, M; Zhang, X; Chen, W; Kan, H; Wu, T. (2014). Urinary metals and heart rate variability: A cross-sectional study of urban adults in Wuhan, China. Environ Health Perspect 123: 217–222. 10.1289/ehp.1307563.25356836
Ferreccio, C; González, C; Milosavjlevic, V; Marshall, G; Sancha, AM; Smith, AH. (2000). Lung cancer and arsenic concentrations in drinking water in Chile. Epidemiology 11: 673–679. 10.1097/00001648-200011000-00010.11055628
Ferreccio, C; Yuan, Y; Calle, J; Benítez, H; Parra, RL; Acevedo, J; Smith, AH; Liaw, J; Steinmaus, C. (2013). Arsenic, tobacco smoke, and occupation: Associations of multiple agents with lung and bladder cancer. Epidemiology 24: 898–905. 10.1097/EDE.0b013e31829e3e03.24036609
Feseke, SK; St-Laurent, J; Anassour-Sidi, E; Ayotte, P; Bouchard, M; Levallois, P. (2015). Arsenic exposure and type 2 diabetes: Results from the 2007-2009 Canadian Health Measures Survey. 35: 63–72.
Flora, SJS. (2011). Arsenic-induced oxidative stress and its reversibility [Review]. Free Radic Biol Med 51: 257–281. 10.1016/j.freeradbiomed.2011.04.008.21554949
Förstermann, U; Sessa, WC. (2012). Nitric oxide synthases: Regulation and function [Review]. Eur Heart J 33: 829–837. 10.1093/eurheartj/ehr304.21890489
Freire, C; Amaya, E; Gil, F; Murcia, M; Llop, S; Casas, M; Vrijheid, M; Lertxundi, A; Irizar, A; Fernández-Tardón, G; Castro-Delgado, RV; Olea, N; Fernández, MF. (2019). Placental metal concentrations and birth outcomes: The Environment and Childhood (INMA) project. Int J Hyg Environ Health 222: 468–478. 10.1016/j.ijheh.2018.12.014.30638867
García-Esquinas, E; Pollán, M; Umans, JG; Francesconi, KA; Goessler, W; Guallar, E; Howard, B; Farley, J; Best, LG; Navas-Acien, A. (2013). Arsenic exposure and cancer mortality in a US-based prospective cohort: The strong heart study. Cancer Epidemiol Biomarkers Prev 22: 1944–1953. 10.1158/1055-9965.EPI-13-0234-T.23800676
Gardner, RM; Kippler, M; Tofail, F; Bottai, M; Hamadani, J; Grandér, M; Nermell, B; Palm, B; Rasmussen, KM; Vahter, M. (2013). Environmental exposure to metals and children’s growth to age 5 years: A prospective cohort study. Am J Epidemiol 177: 1356–1367. 10.1093/aje/kws437.23676282
Gardner, RM; Nermell, B; Kippler, M; Grandér, M; Li, L; Ekström, EC; Rahman, A; Lönnerdal, B; Hoque, AM; Vahter, M. (2011). Arsenic methylation efficiency increases during the first trimester of pregnancy independent of folate status. Reprod Toxicol 31: 210–218. 10.1016/j.reprotox.2010.11.002.21078382
Gelmann, ER; Gurzau, E; Gurzau, A; Goessler, W; Kunrath, J; Yeckel, CW; Mccarty, KM. (2013). A pilot study: The importance of inter-individual differences in inorganic arsenic metabolism for birth weight outcome. Environ Toxicol Pharmacol 36: 1266–1275. 10.1016/j.etap.2013.10.006.24211595
Gentry, PR; Covington, TR; Lawrence, G; McDonald, T; Snow, ET; Germolec, D; Moser, G; Yager, JW; Clewell III, HJ. (2005). Comparison of tissue dosimetry in the mouse following chronic exposure to arsenic compounds. J Toxicol Environ Health A 68: 329–351. 10.1080/15287390590900813.15799626
Gentry, PR; Covington, TR; Mann, S; Shipp, AM; Yager, JW; Clewell, HJ, III. (2004). Physiologically based pharmacokinetic modeling of arsenic in the mouse. J Toxicol Environ Health A 67: 43–71. 10.1080/15287390490253660.14668111
Gerber, GB; Maes, J; Eykens, B. (1982). Transfer of antimony and arsenic to the developing organism. Arch Toxicol 49: 159–168. 10.1007/BF00332363.7059282
Gilbert-Diamond, D; Emond, JA; Baker, ER; Korrick, SA; Karagas, MR. (2016). Relation between in Utero Arsenic Exposure and Birth Outcomes in a Cohort of Mothers and Their Newborns from New Hampshire. Environ Health Perspect 124: 1299–1307. 10.1289/ehp.1510065.26955061
Gilbert, SG; Weiss, B. (2006). A rationale for lowering the blood lead action level from 10 to 2 μg/dL [Review]. Neurotoxicology 27: 693–701. 10.1016/j.neuro.2006.06.008.16889836
Goggin, SL; Labrecque, MT; Allan, AM. (2012). Perinatal exposure to 50 ppb sodium arsenate induces hypothalamic-pituitary-adrenal axis dysregulation in male C57BL/6 mice. Neurotoxicology 33: 1338–1345. 10.1016/j.neuro.2012.08.010.22960421
Gong, G; O’Bryant, SE. (2012). Low-level arsenic exposure, AS3MT gene polymorphism and cardiovascular diseases in rural Texas counties. Environ Res 113: 52–57. 10.1016/j.envres.2012.01.003.22341486
Goodrich, JM; Ingle, ME; Domino, SE; Treadwell, MC; Dolinoy, DC; Burant, C; Meeker, JD; Padmanabhan, V. (2019). First trimester maternal exposures to endocrine disrupting chemicals and metals and fetal size in the Michigan Mother-Infant Pairs study. J Dev Orig Health Dis 10: 1–12. 10.1017/S204017441800106X.30919803
Govarts, E; Remy, S; Bruckers, L; Den Hond, E; Sioen, I; Nelen, V; Baeyens, W; Nawrot, TS; Loots, I; Van Larebeke, N; Schoeters, G. (2016). Combined effects of prenatal exposures to environmental chemicals on birth weight. Int J Environ Res Public Health 13: 495. 10.3390/ijerph13050495.27187434
Grau-Perez, M; Kuo, CC; Gribble, MO; Balakrishnan, P; Jones, S, pratlen, M.; Vaidya, D; Francesconi, KA; Goessler, W; Guallar, E; Silbergeld, EK; Umans, JG; Best, LG; Lee, ET; Howard, BV; Cole, SA; Navas-Acien, A. (2017). Association of low-moderate arsenic exposure and arsenic metabolism with incident diabetes and insulin resistance in the strong heart family study. Environ Health Perspect 125: 127004. 10.1289/EHP2566.29373862
Grau-Pérez, M; Kuo, CC; Spratlen, M; Thayer, KA; Mendez, MA; Hamman, RF; Dabelea, D; Adgate, JL; Knowler, WC; Bell, RA; Miller, FW; Liese, AD; Zhang, C; Douillet, C; Drobná, Z; Mayer-Davis, EJ; Styblo, M; Navas-Acien, A. (2017). The association of arsenic exposure and metabolism with type 1 and type 2 diabetes in youth: the search case-control study. Diabetes Care 40: 46–53. 10.2337/dc16-0810.27810988
Grau-Perez, M; Navas-Acien, A; Galan-Chilet, I; Briongos-Figuero, LS; Morchon-Simon, D; Bermudez, JD; Crainiceanu, CM; de Marco, G; Rentero-Garrido, P; Garcia-Barrera, T; Gomez-Ariza, JL; Casasnovas, JA; Martin-Escudero, JC; Redon, J; Chaves, FJ; Tellez-Plaza, M. (2018). Arsenic exposure, diabetes-related genes and diabetes prevalence in a general population from Spain. Environ Pollut 235: 948–955. 10.1016/j.envpol.2018.01.008.29751399
Gregg, EW; Zhuo, X; Cheng, YJ; Albright, AL; Narayan, KM; Thompson, TJ. (2014). Trends in lifetime risk and years of life lost due to diabetes in the USA, 1985–2011: A modelling study. Lancet Diabetes Endocrinol 2: 867–874. 10.1016/S2213-8587(14)70161-5.25128274
Gribble, MO; Howard, BV; Umans, JG; Shara, NM; Francesconi, KA; Goessler, W; Crainiceanu, CM; Silbergeld, EK; Guallar, E; Navas-Acien, A. (2012). Arsenic exposure, diabetes prevalence, and diabetes control in the strong heart study. Am J Epidemiol 176: 865–874. 10.1093/aje/kws153.23097256
Guan, H; Piao, F; Zhang, X; Li, X; Li, Q; Xu, L; Kitamura, F; Yokoyama, K. (2012). Prenatal exposure to arsenic and its effects on fetal development in the general population of Dalian. Biol Trace Elem Res 149: 10–15. 10.1007/s12011-012-9396-7.22451376
Guha Mazumder, D; Purkayastha, I; Ghose, A; Mistry, G; Saha, C; Nandy, AK; Das, A; Majumdar, KK. (2012). Hypertension in chronic arsenic exposure: A case control study in West Bengal. J Environ Sci Health A Tox Hazard Subst Environ Eng 47: 1514–1520. 10.1080/10934529.2012.680329.22702810
Gunduz, O; Bakar, C; Simsek, C; Baba, A; Elci, A; Gurleyuk, H; Mutlu, M; Cakir, A. (2017). The health risk associated with chronic diseases in villages with high arsenic levels in drinking water supplies. Exposure and Health 9: 261–273. 10.1007/s12403-016-0238-2.
Guo, JX; Hu, L; Yand, PZ; Tanabe, K; Miyatalre, M; Chen, Y. (2007). Chronic arsenic poisoning in drinking water in Inner Mongolia and its associated health effects. J Environ Sci Health A Tox Hazard Subst Environ Eng 42: 1853–1858. 10.1080/10934520701566918.17952786
Hack, M; Klein, NK; Taylor, HG. (1995). Long-term developmental outcomes of low birth weight infants [Review]. Future Child 5: 176–196. 10.2307/1602514.7543353
Hall, EM; Acevedo, J; López, FG; Cortés, S; Ferreccio, C; Smith, AH; Steinmaus, CM. (2017). Hypertension among adults exposed to drinking water arsenic in Northern Chile. Environ Res 153: 99–105. 10.1016/j.envres.2016.11.016.27918984
Hall, M; Gamble, M; Slavkovich, V; Liu, X; Levy, D; Cheng, Z; van Geen, A; Yunus, M; Rahman, M; Pilsner, JR; Graziano, J. (2007). Determinants of arsenic metabolism: Blood arsenic metabolites, plasma folate, cobalamin, and homocysteine concentrations in maternal-newborn pairs. Environ Health Perspect 115: 1503–1509. 10.1289/ehp.9906.17938743
Hamadani, JD; Grantham-Mcgregor, SM; Tofail, F; Nermell, B; Fängström, B; Huda, SN; Yesmin, S; Rahman, M; Vera-Hernández, M; Arifeen, SE; Vahter, M. (2010). Pre- and postnatal arsenic exposure and child development at 18 months of age: A cohort study in rural Bangladesh. Int J Epidemiol 39: 1206–1216. 10.1093/ije/dyp369.20085967
Hamadani, JD; Tofail, F; Nermell, B; Gardner, R; Shiraji, S; Bottai, M; Arifeen, SE; Huda, SN; Vahter, M. (2011). Critical windows of exposure for arsenic-associated impairment of cognitive function in pre-school girls and boys: A population-based cohort study. Int J Epidemiol 40: 1593–1604. 10.1093/ije/dyr176.22158669
Handy, DE; Loscalzo, J. (2022). The role of glutathione peroxidase-1 in health and disease. Free Radic Biol Med 188: 146–161. 10.1016/j.freeradbiomed.2022.06.004.35691509
Hanlon, DP; Ferm, VH. (1987). The concentration and chemical status of arsenic in the early placentas of arsenate-dosed hamsters. Environ Res 42: 546–552. 10.1016/s0013-9351(87)80221-9.3569187
Hansen, AF; Simić, A; Åsvold, BO; Romundstad, PR; Midthjell, K; Syversen, T; Flaten, TP. (2017). Trace elements in early phase type 2 diabetes mellitus-A population-based study. The HUNT study in Norway. J Trace Elem Med Biol 40: 46–53. 10.1016/j.jtemb.2016.12.008.
Hawkesworth, S; Wagatsuma, Y; Kippler, M; Fulford, AJ; Arifeen, SE; Persson, LA; Moore, SE; Vahter, M. (2013). Early exposure to toxic metals has a limited effect on blood pressure or kidney function in later childhood, rural Bangladesh. Int J Epidemiol 42: 176–185. 10.1093/ije/dys215.23243118
Hayden, MR; Tyagi, SC. (2004). Vasa vasorum in plaque angiogenesis, metabolic syndrome, type 2 diabetes mellitus, and atheroscleropathy: a malignant transformation. Cardiovasc Diabetol 3: 1. 10.1186/1475-2840-3-1.14761253
Hays, AM; Lantz, RC; Rodgers, LS; Sollome, JJ; Vaillancourt, RR; Andrew, AS; Hamilton, JW; Camenisch, TD. (2008). Arsenic-induced decreases in the vascular matrix. Toxicol Pathol 36: 805–817. 10.1177/0192623308323919.18812580
He, W; Greenwell, RJ; Brooks, DM; Calderón-Garcidueñas, L; Beall, HD; Coffin, JD. (2007). Arsenic exposure in pregnant mice disrupts placental vasculogenesis and causes spontaneous abortion. Toxicol Sci 99: 244–253. 10.1093/toxsci/kfm162.17569693
Health Canada. (2006). Guidelines for Canadian drinking water quality: Guideline technical document – Arsenic. Ottawa, Ontario: Water Quality and Health Bureau, Healthy Environments and Consumer Safety Branch, Health Canada. http://www.hc-sc.gc.ca/ewh-semt/alt_formats/hecs-sesc/pdf/pubs/water-eau/arsenic/arsenic-eng.pdf.
Heck, JE; Andrew, AS; Onega, T; Rigas, JR; Jackson, BP; Karagas, MR; Duell, EJ. (2009). Lung cancer in a U.S. population with low to moderate arsenic exposure. Environ Health Perspect 117: 1718–1723. 10.1289/ehp.0900566.20049123
Herrera, A; Pineda, J; Antonio, MT. (2013). Toxic effects of perinatal arsenic exposure on the brain of developing rats and the beneficial role of natural antioxidants. Environ Toxicol Pharmacol 36: 73–79. 10.1016/j.etap.2013.03.018.23619517
Hill, AB. (1965). The environment and disease: Association or causation? Proc R Soc Med 58: 295–300. 10.1177/003591576505800503.14283879
Hobbie, K; Shao, K; Henning, C; Mendez, W, Jr; Lee, JS; Cote, I; Druwe, IL; Davis, JA; Gift, JS. (2020). Use of study-specific MOE-like estimates to prioritize health effects from chemical exposure for analysis in human health assessments. Environ Int 144: 105986. 10.1016/j.envint.2020.105986.32871380
Hood, RD; Vedel, GC; Zaworotko, MJ; Tatum, FM; Meeks, RG. (1988). Uptake, distribution, and metabolism of trivalent arsenic in the pregnant mouse. J Toxicol Environ Health 25: 423–434. 10.1080/15287398809531221.3199456
Hopenhayn, C; Ferreccio, C; Browning, SR; Huang, B; Peralta, C; Gibb, H; Hertz-Picciotto, I. (2003). Arsenic exposure from drinking water and birth weight. Epidemiology 14: 593–602. 10.1097/01.ede.0000072104.65240.69.14501275
Hossain, K; Suzuki, T; Hasibuzzaman, MM; Islam, MS; Rahman, A; Paul, SK; Tanu, T; Hossain, S; Saud, ZA; Rahman, M; Nikkon, F; Miyataka, H; Himeno, S; Nohara, K. (2017). Chronic exposure to arsenic, LINE-1 hypomethylation, and blood pressure: a cross-sectional study in Bangladesh. Environ Health 16: 20. 10.1186/s12940-017-0231-7.28270149
Howe, CG; Farzan, SF; Garcia, E; Jursa, T; Iyer, R; Berhane, K; Chavez, TA; Hodes, TL; Grubbs, BH; Funk, WE; Smith, DR; Bastain, TM; Breton, CV. (2020). Arsenic and birth outcomes in a predominately lower income Hispanic pregnancy cohort in Los Angeles. Environ Res 184: 109294. 10.1016/j.envres.2020.109294.32145549
HSDB (Hazardous Substances Data Bank). (2005). Arsenic, Elemental [Database]. Bethesda, MD: National Library of Medicine. Retrieved from http://toxnet.nlm.nih.gov/cgi-bin/sis/htmlgen?HSDB
Hsieh, CY; Wang, SL; Fadrowski, JJ; Navas-Acien, A; Kuo, CC. (2019). Urinary concentration correction methods for arsenic, cadmium, and mercury: A systematic review of practice-based evidence. Curr Environ Health Rep 6: 188–199. 10.1007/s40572-019-00242-8.31372861
Hsieh, FI; Hwang, TS; Hsieh, YC; Lo, HC; Su, CT; Hsu, HS; Chiou, HY; Chen, CJ. (2008a). Risk of erectile dysfunction induced by arsenic exposure through well water consumption in Taiwan. Environ Health Perspect 116: 532–536. 10.1289/ehp.10930.18414639
Hsieh, RL; Huang, YL; Shiue, HS; Huang, SR; Lin, MI; Mu, SC; Chung, CJ; Hsueh, YM. (2014). Arsenic methylation capacity and developmental delay in preschool children in Taiwan. Int J Hyg Environ Health 217: 678–686. 10.1016/j.ijheh.2014.02.004.24698386
Hsieh, Y, -C; Hsieh, F, -I; Lien, L, -M; Chou, Y, -L; Chiou, H, -Y; Chen, C, -J. (2008b). Risk of carotid atherosclerosis associated with genetic polymorphisms of apolipoprotein E and inflammatory genes among arsenic exposed residents in Taiwan. Toxicol Appl Pharmacol 227: 1–7. 10.1016/j.taap.2007.10.013.18022660
Hsieh, Y, -C; Lien, L, -M; Chung, W, -T; Hsieh, F, -I; Hsieh, P, -F; Wu, M, -M; Tseng, H, -P; Chiou, H, -Y; Chen, C, -J. (2011). Significantly increased risk of carotid atherosclerosis with arsenic exposure and polymorphisms in arsenic metabolism genes. Environ Res 111: 804–810. 10.1016/j.envres.2011.05.003.21605854
Hsu, L, -I; Wang, Y, -H; Chiou, H, -Y; Wu, M, -M; Yang, T, -Y; Chen, Y, -H; Tseng, C, -H; Chen, C, -J. (2013). The association of diabetes mellitus with subsequent internal cancers in the arsenic-exposed area of Taiwan. J Asian Earth Sci 73: 452–459. 10.1016/j.jseaes.2013.04.048.
Hsu, L; Chiu, A; Huan, S; Chen, C; Wang, Y; Hsieh, F; Chou, W; Wang, L; Chen, C. (2008). SNPs of GSTM1, T1, P1, epoxide hydrolase and DNA repair enzyme XRCC1 and risk of urinary transitional cell carcinoma in southwestern Taiwan. Toxicol Appl Pharmacol 228: 144–155. 10.1016/j.taap.2007.12.003.18199464
Hsueh, Y, -M; Lin, P; Chen, H, -W; Shiue, H, -S; Chung, C, -J; Tsai, C, -T; Huang, Y, -K; Chiou, H, -Y; Chen, C, -J. (2005). Genetic polymorphisms of oxidative and antioxidant enzymes and arsenic-related hypertension. J Toxicol Environ Health A 68: 1471–1484. 10.1080/15287390590967414.16076760
Hsueh, Y, -M; Wu, W, -L; Huang, Y, -L; Chiou, H, -Y; Tseng, C, -H; Chen, C, -J. (1998). Low serum carotene level and increased risk of ischemic heart disease related to long-term arsenic exposure. Atherosclerosis 141: 249–257. 10.1016/S0021-9150(98)00178-6.9862173
Hsueh, YM; Chen, WJ; Chung, CJ; Hsieh, RL; Chen, HH; Huang, YL; Shiue, HS; Lin, MI; Mu, SC; Lin, YC. (2022). The combined effects of nucleotide-binding domain-like receptor protein 3 polymorphisms and levels of blood lead on developmental delays in preschool children. J Hazard Mater 424: 127317. 10.1016/j.jhazmat.2021.127317.34879550
Hu, X; Zheng, T; Cheng, Y; Holford, T; Lin, S; Leaderer, B; Qiu, J; Bassig, BA; Shi, K; Zhang, Y; Niu, J; Zhu, Y; Li, Y; Guo, H; Chen, Q; Zhang, J; Xu, S; Jin, Y. (2015). Distributions of heavy metals in maternal and cord blood and the association with infant birth weight in China. J Reprod Med 60: 21–29.25745747
Huang, CC; Pan, SC; Chin, WS; Hsu, JF; Guo, YL. (2023). Urinary heavy metals and attentiondeficit/hyperactivity symptoms of preschool children: a mixed-exposure analysis. Ecotoxicol Environ Saf 268: 115714. 10.1016/j.ecoenv.2023.115714.37992648
Huang, CY; Lin, YC; Shiue, HS; Chen, WJ; Su, CT; Pu, YS; Ao, PL; Hsueh, YM. (2018). Comparison of arsenic methylation capacity and polymorphisms of arsenic methylation genes between bladder cancer and upper tract urothelial carcinoma. Toxicol Lett 295: 64–73. 10.1016/j.toxlet.2018.05.035.29859237
Huang, JW; Cheng, YY; Sung, TC; Guo, HR; Sthiannopkao, S. (2014). Association between arsenic exposure and diabetes mellitus in Cambodia. BioMed Res Int 2014: 683124. 10.1155/2014/683124.24949461
Huang, Y, -K; Huang, Y, -L; Hsueh, Y, -M; Yang, M, -H; Wu, M, -M; Chen, S, -Y; Hsu, L, -I; Chen, C, -J. (2008a). Arsenic exposure, urinary arsenic speciation, and the incidence of urothelial carcinoma: A twelve-year follow-up study. Cancer Causes Control 19: 829–839. 10.1007/s10552-008-9146-5.18351295
Huang, Y, -K; Pu, Y, -S; Chung, C, -J; Shiue, H, -S; Yang, M, -H; Chen, C, -J; Hsueh, Y, -M. (2008b). Plasma folate level, urinary arsenic methylation profiles, and urothelial carcinoma susceptibility. Food Chem Toxicol 46: 929–938. 10.1016/j.fct.2007.10.017.18054417
Huang, Y, -K; Tseng, C, -H; Huang, Y, -L; Yang, M, -H; Chen, C, -J; Hsueh, Y, -M. (2007). Arsenic methylation capability and hypertension risk in subjects living in arseniasis-hyperendemic areas in southwestern Taiwan. Toxicol Appl Pharmacol 218: 135–142. 10.1016/j.taap.2006.10.022.17173945
Huang, YL; Hsueh, YM; Huang, YK; Yip, PK; Yang, MH; Chen, CJ. (2009). Urinary arsenic methylation capability and carotid atherosclerosis risk in subjects living in arsenicosis-hyperendemic areas in southwestern Taiwan. Sci Total Environ 407: 2608–2614. 10.1016/j.scitotenv.2008.12.061.19187952
Hughes, MF. (2006). Biomarkers of exposure: A case study with inorganic arsenic [Review]. Environ Health Perspect 114: 1790–1796. 10.1289/ehp.9058.17107869
Huyck, KL; Kile, ML; Mahiuddin, G; Quamruzzaman, Q; Rahman, M; Breton, CV; Dobson, CB; Frelich, J; Hoffman, E; Yousuf, J; Afroz, S; Islam, S; Christiani, DC. (2007). Maternal arsenic exposure associated with low birth weight in Bangladesh. J Occup Environ Med 49: 1097–1104. 10.1097/JOM.0b013e3181566ba0.18000415
IARC (International Agency for Research on Cancer). (2004a). IARC Monographs on the evaluation of carcinogenic risks to humans. Volume 83: Tobacco smoke and involuntary smoking. Lyon, France: World Health Organization, IARC. https://monographs.iarc.fr/wp-content/uploads/2018/06/mono83.pdf.
IARC (International Agency for Research on Cancer). (2004b). Some drinking-water disinfectants and contaminants, including arsenic [IARC Monograph] (pp. 1–477). Lyon, France. http://monographs.iarc.fr/ENG/Monographs/vol84/index.php.
IARC (International Agency for Research on Cancer). (2009). A review of human carcinogens. Part C: Arsenic, metals, fibres, and dusts. In IARC Monographs on the Evaluation of Carcinogenic Risk to Humans. Lyon, France: World Health Organization; International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Monographs/vol100C/mono100C-1.pdf.
IARC (International Agency for Research on Cancer). (2012). Arsenic, metals, fibres and dusts. IARC monographs on the evaluation of carcinogenic risks to humans, vol. 100C: A review of human carcinogens [IARC Monograph]. Lyon, France: World Health Organization. http://monographs.iarc.fr/ENG/Monographs/vol100C/mono100C.pdf.
Islam, MR; Khan, I; Attia, J; Hassan, SMN; Mcevoy, M; D’Este, C; Azim, S; Akhter, A; Akter, S; Shahidullah, SM; Milton, AH. (2012a). Association between hypertension and chronic arsenic exposure in drinking water: A cross-sectional study in Bangladesh. Int J Environ Res Public Health 9: 4522–4536. 10.3390/ijerph9124522.23222207
Islam, R; Khan, I; Hassan, SN; Mcevoy, M; D’Este, C; Attia, J; Peel, R; Sultana, M; Akter, S; Milton, AH. (2012b). Association between type 2 diabetes and chronic arsenic exposure in drinking water: A cross sectional study in Bangladesh. Environ Health 11: 38. 10.1186/1476-069X-11-38.22676249
Jackson, BP; Taylor, VF; Karagas, MR; Punshon, T; Cottingham, KL. (2012). Arsenic, organic foods, and brown rice syrup. Environ Health Perspect 120: 623–626. 10.1289/ehp.1104619.22336149
James, KA; Byers, T; Hokanson, JE; Meliker, JR; Zerbe, GO; Marshall, JA. (2015). Association between Lifetime Exposure to Inorganic Arsenic in Drinking Water and Coronary Heart Disease in Colorado Residents. Environ Health Perspect 123: 128–134. 10.1289/ehp.1307839.25350952
James, KA; Marshall, JA; Hokanson, JE; Meliker, JR; Zerbe, GO; Byers, TE. (2013). A case-cohort study examining lifetime exposure to inorganic arsenic in drinking water and diabetes mellitus. Environ Res 123: 33–38. 10.1016/j.envres.2013.02.005.23507312
Jiang, CB; Kao, CS; Chien, LC; Chen, YJ; Liao, KW. (2022). Associations among prenatal and postnatal arsenic, lead, and cadmium exposures and motor development in 3-year-old children: A longitudinal birth cohort study in Taiwan. Environ Sci Pollut Res Int 29: 43191–43200. 10.1007/s11356-021-18321-5.35091938
Jiang, J; Liu, M; Parvez, F; Wang, B; Wu, F; Eunus, M; Bangalore, S; Newman, JD; Ahmed, A; Islam, T; Rakibuz-Zaman, M; Hasan, R; Sarwar, G; Levy, D; Slavkovich, V; Argos, M; Scannell Bryan, M; Farzan, SF; Hayes, RB; Graziano, JH; Ahsan, H; Chen, Y. (2015). Association between Arsenic Exposure from Drinking Water and Longitudinal Change in Blood Pressure among HEALS Cohort Participants. Environ Health Perspect 123: 806–812. 10.1289/ehp.1409004.25816368
Jomova, K; Jenisova, Z; Feszterova, M; Baros, S; Liska, J; Hudecova, D; Rhodes, CJ; Valko, M. (2011). Arsenic: Toxicity, oxidative stress and human disease [Review]. J Appl Toxicol 31: 95–107. 10.1002/jat.1649.21321970
Jones, MR; Tellez-Plaza, M; Sharrett, AR; Guallar, E; Navas-Acien, A. (2011). Urine arsenic and hypertension in US adults: The 2003-2008 National Health and Nutrition Examination Survey. Epidemiology 22: 153–161. 10.1097/EDE.0b013e318207fdf2.21206367
Kao, C; Fan, Y; Chien, L; Liao, K; Chang, J; Hsu, C; Chen, Y; Jiang, C. (2023a). Effects of preterm birth and postnatal exposure to metal mixtures on neurodevelopment in children at 24 months of age. Environ Sci Pollut Res Int 30: 86856–86865. 10.1007/s11356-023-28450-8.37410323
Kao, C; Fan, Y; Wang, Y; Chen, Y; Chao, H; Lo, Y; Jiang, C; Chien, L. (2023b). Associations between parental and postnatal metal mixture exposure and developmental delays in a Taiwanese longitudinal birth cohort of preschool children. Environ Sci Pollut Res Int 30: 117360–117372. 10.1007/s11356-023-30435-6.37867168
Kao, YH; Yu, CL; Chang, LW; Yu, HS. (2003). Low concentrations of arsenic induce vascular endothelial growth factor and nitric oxide release and stimulate angiogenesis in vitro. Chem Res Toxicol 16: 460–468. 10.1021/tx025652a.12703962
Karagas, MR; Le, CX; Morris, S; Blum, J; Lu, X; Spate, V; Carey, M; Stannard, V; Klaue, B; Tosteson, TD. (2001a). Markers of low level arsenic exposure for evaluating human cancer risks in a US population. Int J Occup Med Environ Health 14: 171–175.11548067
Karagas, MR; Stukel, TA; Morris, JS; Tosteson, TD; Weiss, JE; Spencer, SK; Greenberg, ER. (2001b). Skin cancer risk in relation to toenail arsenic concentrations in a US population-based case-control study. Am J Epidemiol 153: 559–565. 10.1093/aje/153.6.559.11257063
Karagas, MR; Stukel, TA; Tosteson, TD. (2002). Assessment of cancer risk and environmental levels of arsenic in New Hampshire. Int J Hyg Environ Health 205: 85–94. 10.1078/1438-4639-00133.12018020
Karagas, MR; Tosteson, TD; Morris, JS; Demidenko, E; Mott, LA; Heaney, J; Schned, A. (2004). Incidence of transitional cell carcinoma of the bladder and arsenic exposure in New Hampshire. Cancer Causes Control 15: 465–472. 10.1023/B:CACO.0000036452.55199.a3.15286466
Karakis, I; Landau, D; Gat, R; Shemesh, N; Tirosh, O; Yitshak-Sade, M; Sarov, B; Novack, L. (2021). Maternal metal concentration during gestation and pediatric morbidity in children: an exploratory analysis. Environ Health Prev Med 26: 40. 10.1186/s12199-021-00963-z.33765932
Karim, MR; Rahman, M; Islam, K; Mamun, AA; Hossain, S; Hossain, E; Aziz, A; Yeasmin, F; Agarwal, S; Hossain, MI; Saud, ZA; Nikkon, F; Hossain, M; Mandal, A; Jenkins, RO; Haris, PI; Miyataka, H; Himeno, S; Hossain, K. (2013). Increases in oxidized low density lipoprotein and other inflammatory and adhesion molecules with a concomitant decrease in high density lipoprotein in the individuals exposed to arsenic in Bangladesh. Toxicol Sci 135: 17–25. 10.1093/toxsci/kft130.23761297
Kenyon, EM. (2021). Arsenic toxicokinetic modeling and risk analysis: Progress, needs and applications [Review]. Toxicology 457: 152809. 10.1016/j.tox.2021.152809.33965444
Kenyon, EM; Hughes, MF; Adair, BM; Highfill, JH; Crecelius, EA; Clewell, HJ; Yager, JW. (2008). Tissue distribution and urinary excretion of inorganic arsenic and its methylated metabolites in C57BL6 mice following subchronic exposure to arsenate in drinking water. Toxicol Appl Pharmacol 232: 448–455. 10.1016/j.taap.2008.07.018.18706920
Kile, ML; Cardenas, A; Rodrigues, E; Mazumdar, M; Dobson, C; Golam, M; Quamruzzaman, Q; Rahman, M; Christiani, DC. (2016). Estimating Effects of Arsenic Exposure During Pregnancy on Perinatal Outcomes in a Bangladeshi Cohort. Epidemiology 27: 173–181. 10.1097/EDE.0000000000000416.26583609
Kim, NH; Mason, CC; Nelson, RG; Afton, SE; Essader, AS; Medlin, JE; Levine, KE; Hoppin, JA; Lin, C; Knowler, WC; Sandler, DP. (2013). Arsenic exposure and incidence of type 2 diabetes in Southwestern American Indians. Am J Epidemiol 177: 962–969. 10.1093/aje/kws329.23504692
Kim, SS; Meeker, JD; Aung, MT; Yu, Y; Mukherjee, B; Cantonwine, DE; Mcelrath, TF; Ferguson, KK. (2020). Urinary trace metals in association with fetal ultrasound measures during pregnancy. Environmental Epidemiology 4: e075. 10.1097/ee9.0000000000000075.32201854
Kim, Y; Lee, BK. (2011). Association between urinary arsenic and diabetes mellitus in the Korean general population according to KNHANES 2008. Sci Total Environ 409: 4054–4062. 10.1016/j.scitotenv.2011.06.003.21723589
Kippler, M; Wagatsuma, Y; Rahman, A; Nermell, B; Persson, LÅ; Raqib, R; Vahter, M. (2012). Environmental exposure to arsenic and cadmium during pregnancy and fetal size: A longitudinal study in rural Bangladesh. Reprod Toxicol 34: 504–511. 10.1016/j.reprotox.2012.08.002.22985739
Kitchin, KT; Conolly, R. (2010). Arsenic-induced carcinogenesis-oxidative stress as a possible mode of action and future research needs for more biologically based risk assessment [Review]. Chem Res Toxicol 23: 327–335. 10.1021/tx900343d.20035570
Kojima, C; Ramirez, DC; Tokar, EJ; Himeno, S; Drobná, Z; Stýblo, M; Mason, RP; Waalkes, MP. (2009). Requirement of arsenic biomethylation for oxidative DNA damage. J Natl Cancer Inst 101: 1670–1681. 10.1093/Jnci/Djp414.19933942
Kunrath, J; Gurzau, E; Gurzau, A; Goessler, W; Gelmann, ER; Thach, TT; Mccarty, KM; Yeckel, CW. (2013). Blood pressure hyperreactivity: An early cardiovascular risk in normotensive men exposed to low-to-moderate inorganic arsenic in drinking water. J Hypertens 31: 361–369. 10.1097/HJH.0b013e32835c175f.23203141
Kuo, CC; Balakrishnan, P; Gribble, MO; Best, LG; Goessler, W; Umans, JG; Navas-Acien, A. (2022). The association of arsenic exposure and arsenic metabolism with all-cause, cardiovascular and cancer mortality in the Strong Heart Study. Environ Int 159: 107029. 10.1016/j.envint.2021.107029.34890900
Kuo, CC; Howard, BV; Umans, JG; Gribble, MO; Best, LG; Francesconi, KA; Goessler, W; Lee, E; Guallar, E; Navas-Acien, A. (2015). Arsenic exposure, arsenic metabolism, and incident diabetes in the strong heart study. Diabetes Care 38: 620–627. 10.2337/dc14-1641.25583752
Kuo, CC; Su, PH; Sun, CW; Liu, HJ; Chang, CL; Wang, SL. (2018). Early-life arsenic exposure promotes atherogenic lipid metabolism in adolescence: A 15-year birth cohort follow-up study in central Taiwan. Environ Int 118: 97–105. 10.1016/j.envint.2018.05.033.29859944
Kwok, RK; Kaufmann, RB; Jakariya, M. (2006). Arsenic in drinking-water and reproductive health outcomes: A study of participants in the Bangladesh integrated nutrition programme. J Health Popul Nutr 24: 190–205.17195560
Kwok, RK; Mendola, P; Liu, ZY; Savitz, DA; Heiss, G; Ling, HL; Xia, Y; Lobdell, D; Zeng, D; Thorp, JM, Jr; Creason, JP; Mumford, JL. (2007). Drinking water arsenic exposure and blood pressure in healthy women of reproductive age in Inner Mongolia, China. Toxicol Appl Pharmacol 222: 337–343. 10.1016/j.taap.2007.04.003.17509635
Lai, M, -S; Hsueh, Y, -M; Chen, C, -J; Shyu, M, -P; Chen, S, -Y; Kuo, T, -L; Wu, M, -M; Tai, T, -Y. (1994). Ingested inorganic arsenic and prevalence of diabetes mellitus. Am J Epidemiol 139: 484–492.8154472
Laine, JE; Bailey, KA; Rubio-Andrade, M; Olshan, AF; Smeester, L; Drobná, Z; Herring, AH; Stýblo, M; García-Vargas, GG; Fry, RC. (2015). Maternal Arsenic Exposure, Arsenic Methylation Efficiency, and Birth Outcomes in the Biomarkers of Exposure to ARsenic (BEAR) Pregnancy Cohort in Mexico. Environ Health Perspect 123: 186–192. 10.1289/ehp.1307476.25325819
Lampron-Goulet, É; Gagnon, F; Langlois, MF. (2017). Association between consumption of private well water contaminated by low levels of arsenic and dysglycemia in a rural region of Quebec, Canada. Environ Res 159: 232–238. 10.1016/j.envres.2017.07.049.28818805
Lau, A; Whitman, SA; Jaramillo, MC; Zhang, DD. (2013). Arsenic-mediated activation of the Nrf2-Keap1 antioxidant pathway [Review]. J Biochem Mol Toxicol 27: 99–105. 10.1002/jbt.21463.23188707
Lawlor, DA; Tilling, K; Smith, GD. (2016). Triangulation in aetiological epidemiology. Int J Epidemiol 1866–1886. 10.1093/ije/dyw314.
Lee, MS; Eum, KD; Golam, M; Quamruzzaman, Q; Kile, ML; Mazumdar, M; Christiani, DC. (2021). Umbilical cord blood metal mixtures and birth size in Bangladeshi children. Environ Health Perspect 129: 57006. 10.1289/EHP7502.33989040
Lee, MY; Jung, BI; Chung, SM; Bae, ON; Lee, JY; Park, JD; Yang, JS; Lee, H; Chung, JH. (2003). Arsenic-induced dysfunction in relaxation of blood vessels. Environ Health Perspect 111: 513–517. 10.1289/ehp.5916.12676608
Lemaire, M; Lemarié, CA; Molina, MF; Schiffrin, EL; Lehoux, S; Mann, KK. (2011). Exposure to moderate arsenic concentrations increases atherosclerosis in ApoE-/- mouse model. Toxicol Sci 122: 211–221. 10.1093/toxsci/kfr097.21512104
Leong, T; Zylberstein, D; Graham, I; Lissner, L; Ward, D; Fogarty, J; Bengtsson, C; Björkelund, C; Thelle, D; Collaboration, S-I-N. (2008). Asymmetric dimethylarginine independently predicts fatal and nonfatal myocardial infarction and stroke in women: 24-year follow-up of the population study of women in Gothenburg. Arterioscler Thromb Vasc Biol 28: 961–967. 10.1161/ATVBAHA.107.156596.18292394
Lewis, DR; Southwick, JW; Ouellet-Hellstrom, R; Rench, J; Calderon, RL. (1999). Drinking water arsenic in Utah: A cohort mortality study. Environ Health Perspect 107: 359–365. 10.2307/3434539.10210691
Li, CS; Loch-Caruso, R. (2007). Sodium arsenite inhibits migration of extravillous trophoblast cells in vitro. Reprod Toxicol 24: 296–302. 10.1016/j.reprotox.2007.06.002.17646079
Li, G; Lee, LS; Li, M; Tsao, SW; Chiu, JF. (2011). Molecular changes during arsenic-induced cell transformation. J Cell Physiol 226: 3225–3232. 10.1002/jcp.22683.21344382
Li, L; Ekström, EC; Goessler, W; Lönnerdal, B; Nermell, B; Yunus, M; Rahman, A; El Arifeen, S; Persson, LA; Vahter, M. (2008). Nutritional status has marginal influence on the metabolism of inorganic arsenic in pregnant Bangladeshi women. Environ Health Perspect 116: 315–321. 10.1289/ehp.10639.18335097
Li, W, -F; Sun, C, -W; Cheng, T, -J; Chang, K, -H; Chen, C, -J; Wang, S, -L. (2009). Risk of carotid atherosclerosis is associated with low serum paraoxonase (PON1) activity among arsenic exposed residents in Southwestern Taiwan. Toxicol Appl Pharmacol 236: 246–253. 10.1016/j.taap.2009.01.019.19371607
Li, X; Li, B; Xi, S; Zheng, Q; Lv, X; Sun, G. (2013a). Prolonged environmental exposure of arsenic through drinking water on the risk of hypertension and type 2 diabetes. Environ Sci Pollut Res Int 20: 8151–8161. 10.1007/s11356-013-1768-9.23649600
Li, X; Li, B; Xi, S; Zheng, Q; Wang, D; Sun, G. (2013b). Association of urinary monomethylated arsenic concentration and risk of hypertension: A cross-sectional study from arsenic contaminated areas in northwestern China. Environ Health 12: 37. 10.1186/1476-069X-12-37.23602086
Li, XT; Yu, PF; Gao, Y; Guo, WH; Wang, J; Liu, X; Gu, AH; Ji, GX; Dong, Q; Wang, BS; Cao, Y; Zhu, BL; Xiao, H. (2017). Association between plasma metal levels and diabetes risk: A case-control study in China. Biomed Environ Sci 30: 482–491. 10.3967/bes2017.064.28756807
Li, Y, -N; Xi, M, -M; Guo, Y; Hai, C, -X; Yang, W, -L; Qin, X, -J. (2014). NADPH oxidase-mitochondria axis-derived ROS mediate arsenite-induced HIF-1α stabilization by inhibiting prolyl hydroxylases activity. Toxicol Lett 224: 165–174. 10.1016/j.toxlet.2013.10.029.24188932
Li, Y; Wang, D; Li, X; Zheng, Q; Sun, G. (2015). A potential synergy between incomplete arsenic methylation capacity and demographic characteristics on the risk of hypertension: findings from a cross-sectional study in an arsenic-endemic area of inner Mongolia, China. Int J Environ Res Public Health 12: 3615–3632. 10.3390/ijerph120403615.25837203
Liang, C; Wu, X; Huang, K; Yan, S; Li, Z; Xia, X; Pan, W; Sheng, J; Tao, R; Tao, Y; Xiang, H; Hao, J; Wang, Q; Tong, S; Tao, F. (2020). Domain- and sex-specific effects of prenatal exposure to low levels of arsenic on children’s development at 6 months of age: Findings from the Ma’anshan birth cohort study in China. Environ Int 135: 105112. 10.1016/j.envint.2019.105112.31881426
Liao, KW; Chang, CH; Tsai, MS; Chien, LC; Chung, MY; Mao, IF; Tsai, YA; Chen, ML. (2018). Associations between urinary total arsenic levels, fetal development, and neonatal birth outcomes: A cohort study in Taiwan. Sci Total Environ 612: 1373–1379. 10.1016/j.scitotenv.2017.08.312.28898944
Liao, Y, -T; Chen, C, -J; Li, W, -F; Hsu, L, -Y; Tsai, L, -Y; Huang, Y, -L; Sun, C, -W; Chen, WJ; Wang, S, -L. (2012). Elevated lactate dehydrogenase activity and increased cardiovascular mortality in the arsenic-endemic areas of southwestern Taiwan. Toxicol Appl Pharmacol 262: 232–237. 10.1016/j.taap.2012.04.028.22569360
Liao, YT; Li, WF; Chen, CJ; Prineas, RJ; Chen, WJ; Zhang, ZM; Sun, CW; Wang, SL. (2009). Synergistic effect of polymorphisms of paraoxonase gene cluster and arsenic exposure on electrocardiogram abnormality. Toxicol Appl Pharmacol 239: 178–183. 10.1016/j.taap.2008.12.017.19152805
Libby, P; Ridker, PM; Hansson, GK. (2011). Progress and challenges in translating the biology of atherosclerosis [Review]. Nature 473: 317–325. 10.1038/nature10146.21593864
Lin, HC; Huang, YK; Shiue, HS; Chen, LS; Choy, CS; Huang, SR; Han, BC; Hsueh, YM. (2014). Arsenic methylation capacity and obesity are associated with insulin resistance in obese children and adolescents. Food Chem Toxicol 74C: 60–67. 10.1016/j.fct.2014.08.018.
Lin, YC; Chen, WJ; Huang, CY; Shiue, HS; Su, CT; Ao, PL; Pu, YS; Hsueh, YM. (2018). Polymorphisms of arsenic (+3 oxidation state) methyltransferase and arsenic methylation capacity affect the risk of bladder cancer. Toxicol Sci 164: 328–338. 10.1093/toxsci/kfy087.29669044
Linakis, MW; Van Landingham, C; Gasparini, A, . . (2024). Re-expressing coefficients from regression models for inclusion in a meta-analysis. BMC Med Res Methodol 24. 10.1186/s12874-023-02132-y.
Lind, L; Araujo, JA; Barchowsky, A; Belcher, S; Berridge, BR; Chiamvimonvat, N; Chiu, WA; Cogliano, VJ; Elmore, S; Farraj, AK; Gomes, AV; McHale, CM; Meyer-Tamaki, KB; Posnack, NG; Vargas, HM; Yang, X; Zeise, L; Zhou, C; Smith, MT. (2021). Key characteristics of cardiovascular toxicants. Environ Health Perspect 129: 95001. 10.1289/EHP9321.34558968
Lisabeth, LD; Ahn, HJ; Chen, JJ; Sealy-Jefferson, S; Burke, JF; Meliker, JR. (2010). Arsenic in drinking water and stroke hospitalizations in Michigan. Stroke 41: 2499–2504. 10.1161/STROKEAHA.110.585281.20947858
Liu-Mares, W; Mackinnon, JA; Sherman, R; Fleming, LE; Rocha-Lima, C; Hu, JJ; Lee, DJ. (2013). Pancreatic cancer clusters and arsenic-contaminated drinking water wells in Florida. BMC Cancer 13: 111. 10.1186/1471-2407-13-111.23510413
Liu, B; Feng, W; Wang, J; Li, Y; Han, X; Hu, H; Guo, H; Zhang, X; He, M. (2016). Association of urinary metals levels with type 2 diabetes risk in coke oven workers. Environ Pollut 210: 1–8. 10.1016/j.envpol.2015.11.046.26689646
Liu, H; Lu, S; Zhang, B; Xia, W; Liu, W; Peng, Y; Zhang, H; Wu, K; Xu, S; Li, Y. (2018). Maternal arsenic exposure and birth outcomes: A birth cohort study in Wuhan, China. Environ Pollut 236: 817–823. 10.1016/j.envpol.2018.02.012.29462776
Liu, LZ; Jiang, Y; Carpenter, RL; Jing, Y; Peiper, SC; Jiang, BH. (2011). Role and mechanism of arsenic in regulating angiogenesis. PLoS ONE 6: e20858. 10.1371/journal.pone.0020858.21687637
Liu, S; Guo, X; Wu, B; Yu, H; Zhang, X; Li, M. (2014). Arsenic induces diabetic effects through beta-cell dysfunction and increased gluconeogenesis in mice. Sci Rep 4: 6894. 10.1038/srep06894.25367288
Lloyd-Jones, DM; Larson, MG; Beiser, A; Levy, D. (1999). Lifetime risk of developing coronary heart disease. Lancet 353: 89–92. 10.1016/S0140-6736(98)10279-9.10023892
Loomans, CJM; de Koning, EJP; Staal, FJT; Rookmaaker, MB; Verseyden, C; de Boer, HC; Verhaar, MC; Braam, B; Rabelink, TJ; van Zonneveld, AJ. (2004). Endothelial progenitor cell dysfunction - A novel concept in the pathogenesis of vascular complications of type 1 diabetes. Diabetes 53: 195–199.14693715
Louis, GMB; Smarr, MM; Sundaram, R; Steuerwald, AJ; Sapra, KJ; Lu, ZH; Parsons, PJ. (2017). Low-level environmental metals and metalloids and incident pregnancy loss. Reprod Toxicol 69: 68–74. 10.1016/j.reprotox.2017.01.011.28163209
Lozano, M; Broberg, K; Soler-Blasco, R; Riutort-Mayol, G; Ballester, F; González, L; Murcia, M; Grimalt, J; Gil, F; Olmedo, P; Braeuer, S; Casas, M; Guxens, M; Irizar, A; Lertxundi, N; Zubero, M; Marina, L; Llop, S. (2024). Prenatal Metals Exposure and pre-adolescents’ Emotional and Behavioral Problems. Exposure and Health 16: 679–692. 10.1007/s12403-023-00585-6.
Lucchini, RG; Guazzetti, S; Renzetti, S; Conversano, M; Cagna, G; Fedrighi, C; Giorgino, A; Peli, M; Placidi, D; Zoni, S; Forte, G; Majorani, C; Pino, A; Senofonte, O; Petrucci, F; Alimonti, A. (2019). Neurocognitive impact of metal exposure and social stressors among schoolchildren in Taranto, Italy. Environ Health 18: 67. 10.1186/s12940-019-0505-3.31324194
Luo, J; Qiu, Z; Chen, J; Zhang, L; Liu, W; Tan, Y; Shu, W. (2013). Maternal and early life arsenite exposure impairs neurodevelopment and increases the expression of PSA-NCAM in hippocampus of rat offspring. Toxicology 311: 99–106. 10.1016/j.tox.2013.06.007.23811142
Luo, YW; Mccullough, LE; Tzeng, JY; Darrah, T; Vengosh, A; Maguire, RL; Maity, A; Samuel-Hodge, C; Murphy, SK; Mendez, MA; Hoyo, C. (2017). Maternal blood cadmium, lead and arsenic levels, nutrient combinations, and offspring birthweight. BMC Public Health 17: 354. 10.1186/s12889-017-4225-8.28438148
Lynch, HN; Zu, K; Kennedy, EM; Lam, T; Liu, X; Pizzurro, DM; Loftus, CT; Rhomberg, LR. (2017a). Corrigendum to &quot;Quantitative assessment of lung and bladder cancer risk and oral exposure to inorganic arsenic: Meta-regression analyses of epidemiological data&quot; Environmental International 106 :178-206 [Erratum]. Environ Int 109: 195–196. 10.1016/j.envint.2017.10.004.29078863
Lynch, HN; Zu, K; Kennedy, EM; Lam, T; Liu, X; Pizzurro, DM; Loftus, CT; Rhomberg, LR. (2017b). Quantitative assessment of lung and bladder cancer risk and oral exposure to inorganic arsenic: Meta-regression analyses of epidemiological data. Environ Int 106: 178–206. 10.1016/j.envint.2017.04.008.28625818
Lynn, S; Gurr, J, -R; Lai, H, -T; Jan, K, -Y. (2000). NADH oxidase activation is involved in arsenite-induced oxidative DNA damage in human vascular smooth muscle cells. Circ Res 86: 514–519. 10.1161/01.RES.86.5.514.10720412
Ma, JH; Geng, SJ; Sun, Q; Zhang, X; Han, LX; Yao, XD; Zhang, BQ; Zhu, LJ; Wen, J. (2023). Exposure to metal mixtures and young children’s growth and development: A biomonitoring-based study in Eastern China. Ecotoxicol Environ Saf 268: 115726. 10.1016/j.ecoenv.2023.115726.37992646
Makhani, K; Chiavatti, C; Plourde, D; Negro Silva, LF; Lemaire, M; Lemarié, CA; Lehoux, S; Mann, KK. (2018). Using the Apolipoprotein E Knock-Out Mouse Model to Define Atherosclerotic Plaque Changes Induced by Low Dose Arsenic. Toxicol Sci 166: 213–218. 10.1093/toxsci/kfy201.30376133
Malin Igra, A; Warnqvist, A; Rahman, SM; Ekström, EC; Rahman, A; Vahter, M; Kippler, M. (2021). Environmental metal exposure and growth to 10 years of age in a longitudinal mother-child cohort in rural Bangladesh. Environ Int 156: 106738. 10.1016/j.envint.2021.106738.34246127
Mann, S; Droz, PO; Vahter, M. (1996a). A physiologically based pharmacokinetic model for arsenic exposure: I. Development in hamsters and rabbits. Toxicol Appl Pharmacol 137: 8–22. 10.1006/taap.1996.0052.8607145
Mann, S; Droz, PO; Vahter, M. (1996b). A physiologically based pharmacokinetic model for arsenic exposure: II. Validation and application in humans. Toxicol Appl Pharmacol 140: 471–486. 10.1006/taap.1996.0244.8887465
Mantha, M; Yeary, E; Trent, J; Creed, PA; Kubachka, K; Hanley, T; Shockey, N; Heitkemper, D; Caruso, J; Xue, J; Rice, G; Wymer, L; Creed, JT. (2016). Estimating inorganic arsenic exposure from U.S. rice and total water intakes. Environ Health Perspect 125: 057005. 10.1289/EHP418.
Marchiset-Ferlay, N; Savanovitch, C; Sauvant-Rochat, MP. (2012). What is the best biomarker to assess arsenic exposure via drinking water? [Review]. Environ Int 39: 150–171. 10.1016/j.envint.2011.07.015.22208756
Marlowe, M; Cossairt, A; Moon, C; Errera, J; Macneel, A; Peak, R; Ray, J; Schroeder, C. (1985). Main and interaction effects of metallic toxins on classroom behavior. J Abnorm Child Psychol 13: 185–198. 10.1007/BF00910641.4008752
Martin, EM; Stýblo, M; Fry, RC. (2017). Genetic and epigenetic mechanisms underlying arsenic-associated diabetes mellitus: a perspective of the current evidence [Review]. Epigenomics 9: 701–710. 10.2217/epi-2016-0097.28470093
Martinez-Finley, EJ; Ali, AMS; Allan, AM. (2009). Learning deficits in C57BL/6J mice following perinatal arsenic exposure: Consequence of lower corticosterone receptor levels. Pharmacol Biochem Behav 94: 271–277. 10.1016/j.pbb.2009.09.006.19751756
Martinez-Finley, EJ; Goggin, SL; Labrecque, MT; Allan, AM. (2011). Reduced expression of MAPK/ERK genes in perinatal arsenic-exposed offspring induced by glucocorticoid receptor deficits. Neurotoxicol Teratol 33: 530–537. 10.1016/j.ntt.2011.07.003.21784148
Martinez-Morata, I; Sobel, M; Tellez-Plaza, M; Navas-Acien, A; Howe, CG; Sanchez, TR. (2023). A state-of-the-science review on metal biomarkers [Review]. Curr Environ Health Rep 10: 215–249. 10.1007/s40572-023-00402-x.37337116
Martinez, EJ; Kolb, BL; Bell, A; Savage, DD; Allan, AM. (2008). Moderate perinatal arsenic exposure alters neuroendocrine markers associated with depression and increases depressive-like behaviors in adult mouse offspring. Neurotoxicology 29: 647–655. 10.1016/j.neuro.2008.05.004.18573533
Massrieh, W; Derjuga, A; Blank, V. (2006). Induction of endogenous Nrf2/small maf heterodimers by arsenic-mediated stress in placental choriocarcinoma cells. Antioxid Redox Signal 8: 53–59. 10.1089/ars.2006.8.53.16487037
Mateen, FJ; Grau-Perez, M; Pollak, JS; Moon, KA; Howard, BV; Umans, JG; Best, LG; Francesconi, KA; Goessler, W; Crainiceanu, C; Guallar, E; Devereux, RB; Roman, MJ; Navas-Acien, A. (2017). Chronic arsenic exposure and risk of carotid artery disease: The Strong Heart Study. Environ Res 157: 127–134. 10.1016/j.envres.2017.05.020.28554006
Maull, EA; Ahsan, H; Edwards, J; Longnecker, MP; Navas-Acien, A; Pi, J; Silbergeld, EK; Styblo, M; Tseng, CH; Thayer, KA; Loomis, D. (2012). Evaluation of the association between arsenic and diabetes: A National Toxicology Program workshop review [Review]. Environ Health Perspect 120: 1658–1670. 10.1289/ehp.1104579.22889723
Mcdermott, S; Bao, W; Aelion, CM; Cai, B; Lawson, AB. (2014). Does the metal content in soil around a pregnant woman’s home increase the risk of low birth weight for her infant? Environ Geochem Health 36: 1191–1197. 10.1007/s10653-014-9617-4.24771409
Mcdermott, S; Wu, J; Cai, B; Lawson, A; Marjorie Aelion, C. (2011). Probability of intellectual disability is associated with soil concentrations of arsenic and lead. Chemosphere 84: 31–38. 10.1016/j.chemosphere.2011.02.088.21450328
Medrano, MJ; Boix, R; Pastor-Barriuso, R; Palau, M; Damián, J; Ramis, R; del Barrio, JL; Navas-Acien, A. (2010). Arsenic in public water supplies and cardiovascular mortality in Spain. Environ Res 110: 448–454. 10.1016/j.envres.2009.10.002.19880104
Meliker, J. R.; Slotnick, MJ; Avruskin, GA; Schottenfeld, D; Jacquez, GM; Wilson, ML; Goovaerts, P; Franzblau, A; Nriagu, JO. (2010). Lifetime exposure to arsenic in drinking water and bladder cancer: A population-based case-control study in Michigan, USA. Cancer Causes Control 21: 745–757. 10.1007/s10552-010-9503-z.20084543
Mendez, MA; González-Horta, C; Sánchez-Ramírez, B; Ballinas-Casarrubias, L; Cerón, RH; Morales, DV; Terrazas, FA; Ishida, MC; Gutiérrez-Torres, DS; Saunders, RJ; Drobná, Z; Fry, RC; Buse, JB; Loomis, D; García-Vargas, GG; Del Razo, LM; Stýblo, M. (2016). Chronic Exposure to Arsenic and Markers of Cardiometabolic Risk: A Cross-Sectional Study in Chihuahua, Mexico. Environ Health Perspect 124: 104–111. 10.1289/ehp.1408742.26068977
Mendez, W, Jr; Shao, K; Lee, JS; Cote, I; Druwe, IL; Davis, A; Gift, JS. (2020). Model averaging methods for the evaluation of dose-response model uncertainty when assessing the suitability of studies for estimating risk. Environ Int 143: 105857. 10.1016/j.envint.2020.105857.32615345
Mendez, WM; Eftim, S; Cohen, J; Warren, I; Cowden, J; Lee, JS; Sams, R. (2017). Relationships between arsenic concentrations in drinking water and lung and bladder cancer incidence in U.S. counties. J Expo Sci Environ Epidemiol 27: 235–243. 10.1038/jes.2016.58.27901016
Meng, D; Wang, X; Chang, Q; Hitron, A; Zhang, Z; Xu, M; Chen, G; Luo, J; Jiang, B; Fang, J; Shi, X. (2010). Arsenic promotes angiogenesis in vitro via a heme oxygenase-1-dependent mechanism. Toxicol Appl Pharmacol 244: 291–299. 10.1016/j.taap.2010.01.004.20083128
Merrill, PD; Ampah, SB; He, K; Rembert, NJ; Brockman, J; Kleindorfer, D; McClure, LA. (2017). Association between trace elements in the environment and stroke risk: The reasons for geographic and racial differences in stroke (REGARDS) study. J Trace Elem Med Biol 42: 45–49. 10.1016/j.jtemb.2017.04.003.28595791
Michaud, DS; Wright, ME; Cantor, KP; Taylor, PR; Virtamo, J; Albanes, D. (2004). Arsenic concentrations in prediagnostic toenails and the risk of bladder cancer in a cohort study of male smokers. Am J Epidemiol 160: 853–859. 10.1093/aje/kwh295.15496537
Milton, AH; Smith, W; Rahman, B; Hasan, Z; Kulsum, U; Dear, K; Rakibuddin, M; Ali, A. (2005). Chronic arsenic exposure and adverse pregnancy outcomes in Bangladesh. Epidemiology 16: 82–86. 10.1097/01.ede.0000147105.94041.e6.15613949
Mirkes, PE; Little, SA. (1998). Teratogen-induced cell death in postimplantation mouse embryos: differential tissue sensitivity and hallmarks of apoptosis. Cell Death Differ 5: 592–600. 10.1038/sj.cdd.4400390.10200514
Monrad, M; Ersbøll, AK; Sørensen, M; Baastrup, R; Hansen, B; Gammelmark, A; Tjønneland, A; Overvad, K; Raaschou-Nielsen, O. (2017). Low-level arsenic in drinking water and risk of incident myocardial infarction: A cohort study. Environ Res 154: 318–324. 10.1016/j.envres.2017.01.028.28157645
Moon, K; Guallar, E; Navas-Acien, A. (2012). Arsenic exposure and cardiovascular disease: An updated systematic review. Curr Atheroscler Rep 14: 542–555. 10.1007/s11883-012-0280-x.22968315
Moon, KA; Guallar, E; Umans, JG; Devereux, RB; Best, LG; Francesconi, KA; Goessler, W; Pollak, J; Silbergeld, EK; Howard, BV; Navas-Acien, A. (2013). Association between exposure to low to moderate arsenic levels and incident cardiovascular disease: A prospective cohort study. Ann Intern Med 159: 649–659. 10.7326/0003-4819-159-10-201311190-00719.24061511
Moon, KA; Navas-Acien, A; Grau-Pérez, M; Francesconi, KA; Goessler, W; Guallar, E; Umans, JG; Best, LG; Newman, JD. (2017a). Low-moderate urine arsenic and biomarkers of thrombosis and inflammation in the Strong Heart Study. PLoS ONE 12: e0182435. 10.1371/journal.pone.0182435.28771557
Moon, KA; Oberoi, S; Barchowsky, A; Chen, Y; Guallar, E; Nachman, KE; Rahman, M; Sohel, N; D’Ippoliti, D; Wade, TJ; James, KA; Farzan, SF; Karagas, MR; Ahsan, H; Navas-Acien, A. (2017b). A dose-response meta-analysis of chronic arsenic exposure and incident cardiovascular disease [Review]. Int J Epidemiol 46: 1924–1939. 10.1093/ije/dyx202.29040626
Moon, KA; Zhang, Y; Guallar, E; Francesconi, KA; Goessler, W; Umans, JG; Best, LG; Howard, BV; Devereux, RB; Okin, PM; Navas-Acien, A. (2018). Association of low-moderate urine arsenic and QT interval: Cross-sectional and longitudinal evidence from the Strong Heart Study. Environ Pollut 240: 894–902. 10.1016/j.envpol.2018.04.129.29793197
Mordukhovich, I; Wright, RO; Amarasiriwardena, C; Baja, E; Baccarelli, A; Suh, H; Sparrow, D; Vokonas, P; Schwartz, J. (2009). Association between low-level environmental arsenic exposure and QT interval duration in a general population study. Am J Epidemiol 170: 739–746. 10.1093/aje/kwp191.19700500
Mostafa, MG; McDonald, JC; Cherry, NM. (2008). Lung cancer and exposure to arsenic in rural Bangladesh. Occup Environ Med 65: 765–768. 10.1136/oem.2007.037895.18417558
Mullin, AM; Amarasiriwardena, C; Cantoral-Preciado, A; Claus Henn, B; Leon Hsu, HH; Sanders, AP; Svensson, K; Tamayo-Ortiz, M; Téllez-Rojo, MM; Wright, RO; Burris, HH. (2019). Maternal blood arsenic levels and associations with birth weight-for-gestational age. Environ Res 177: 108603. 10.1016/j.envres.2019.108603.31357156
Mumford, JL; Wu, K; Xia, Y; Kwok, R; Yang, Z; Foster, J; Sanders, WE, Jr. (2007). Chronic arsenic exposure and cardiac repolarization abnormalities with QT interval prolongation in a population-based study. Environ Health Perspect 115: 690–694. 10.1289/ehp.9686.17520054
Muse, ME; Li, Z; Baker, ER; Cottingham, KL; Korrick, SA; Karagas, MR; Gilbert-Diamond, D. (2020). Relation between in utero arsenic exposure and growth during the first year of life in a New Hampshire pregnancy cohort. Environ Res 180: 108604. 10.1016/j.envres.2019.108604.31710845
Myers, SL; Lobdell, DT; Liu, Z; Xia, Y; Ren, H; Li, Y; Kwok, RK; Mumford, JL; Mendola, P. (2010). Maternal drinking water arsenic exposure and perinatal outcomes in Inner Mongolia, China. J Epidemiol Community Health 64: 325–329. 10.1136/jech.2008.084392.19692727
Nabgha-e-Amen; Eqani, S; Khuram, F; Alamdar, A; Tahir, A; Shah, STA; Nasir, A; Javed, S; Bibi, N; Hussain, A; Rasheed, H; Shen, H. (2020). Environmental exposure pathway analysis of trace elements and autism risk in Pakistani children population. Sci Total Environ 712: 136471. 10.1016/j.scitotenv.2019.136471.31927446
Nahar, MN; Inaoka, T; Fujimura, M. (2014a). A consecutive study on arsenic exposure and intelligence quotient (IQ) of children in Bangladesh. Environ Health Prev Med 19: 194–199. 10.1007/s12199-013-0374-2.24368742
Nahar, MN; Inaoka, T; Fujimura, M; Watanabe, C; Shimizu, H; Tasnim, S; Sultana, N. (2014b). Arsenic contamination in groundwater and its effects on adolescent intelligence and social competence in Bangladesh with special reference to daily drinking/cooking water intake. Environ Health Prev Med 19: 151–158. 10.1007/s12199-013-0369-z.24254803
NASEM (National Academies of Sciences, Engineering, and Medicine). (2019). Review of EPA’s updated problem formulation and protocol for the inorganic arsenic IRIS assessment. Washington, DC: The National Academies Press. 10.17226/25558.
NASEM (National Academies of Sciences, Engineering, and Medicine). (2021). Review of U.S. EPA’s ORD staff handbook for developing IRIS assessments: 2020 version. Washington, DC: National Academies Press. 10.17226/26289.
Navas-Acien, A; Silbergeld, EK; Pastor-Barriuso, R; Guallar, E. (2008). Arsenic exposure and prevalence of type 2 diabetes in US adults. JAMA 300: 814–822. 10.1001/jama.300.7.814.18714061
Navas-Acien, A; Silbergeld, EK; Pastor-Barriuso, R; Guallar, E. (2009a). Rejoinder: Arsenic exposure and prevalence of type 2 diabetes: Updated findings from the National Health Nutrition and Examination Survey, 2003-2006 [Comment]. Epidemiology 20: 816–820. 10.1097/EDE.0b013e3181afef88.19713856
Navas-Acien, A; Silbergeld, EK; Streeter, RA; Clark, JM; Burke, TA; Guallar, E. (2006). Arsenic exposure and type 2 diabetes: a systematic review of the experimental and epidemiological evidence [Review]. Environ Health Perspect 114: 641–648. 10.1289/ehp.8551.16675414
Navas-Acien, A; Umans, JG; Howard, BV; Goessler, W; Francesconi, KA; Crainiceanu, CM; Silbergeld, EK; Guallar, E. (2009b). Urine arsenic concentrations and species excretion patterns in American Indian communities over a 10-year period: The Strong Heart Study. Environ Health Perspect 117: 1428–1433. 10.1289/ehp.0800509.19750109
Newman, JD; Navas-Acien, A; Kuo, CC; Guallar, E; Howard, BV; Fabsitz, RR; Devereux, RB; Umans, JG; Francesconi, KA; Goessler, W; Best, LT; Tellez-Plaza, M. (2016). Peripheral Arterial Disease and Its Association With Arsenic Exposure and Metabolism in the Strong Heart Study. Am J Epidemiol 184: 806–817. 10.1093/aje/kww002.27810857
Nigra, AE; Moon, KA; Jones, MR; Sanchez, TR; Navas-Acien, A. (2021). Urinary arsenic and heart disease mortality in NHANES 2003-2014. Environ Res 200: 111387. 10.1016/j.envres.2021.111387.34090890
Nizam, S; Kato, M; Yatsuya, H; Khalequzzaman, M; Ohnuma, S; Naito, H; Nakajima, T. (2013). Differences in urinary arsenic metabolites between diabetic and non-diabetic subjects in Bangladesh. Int J Environ Res Public Health 10: 1006–1019. 10.3390/ijerph10031006.23481591
Nong, Q; Zhang, Y; Guallar, E; Zhong, Q. (2016). Arsenic exposure and predicted 10-year atherosclerotic cardiovascular risk using the pooled cohort equations in U.S. hypertensive adults. Int J Environ Res Public Health 13. 10.3390/ijerph13111093.
Nozadi, SS; Li, L; Luo, L; Mackenzie, D; Erdei, E; Du, R; Roman, CW; Hoover, J; O’Donald, E; Burnette, C; Lewis, J. (2021). Prenatal metal exposures and infants’ developmental outcomes in a Navajo population. Int J Environ Res Public Health 19: 425. 10.3390/ijerph19010425.35010683
NRC (National Research Council). (1999). Arsenic in drinking water. Washington, DC: National Academy Press. http://www.nap.edu/catalog/6444.html.
NRC (National Research Council). (2001). Arsenic in drinking water: 2001 update. Washington, DC: National Academy Press. http://www.nap.edu/openbook.php?record_id=10194&page=R1.
NRC (National Research Council). (2009). Science and decisions: Advancing risk assessment. Washington, DC: National Academies Press. 10.17226/12209.
NRC (National Research Council). (2011). Review of the Environmental Protection Agency’s draft IRIS assessment of formaldehyde (pp. 1–194). Washington, DC: The National Academies Press. 10.17226/13142.
NRC (National Research Council). (2013). Critical aspects of EPA’s IRIS assessment of inorganic arsenic: Interim report. Washington, DC: The National Academies Press. https://www.nap.edu/catalog/18594/critical-aspects-of-epas-iris-assessment-of-inorganic-arsenic-interim.
NRC (National Research Council). (2014). Review of EPA’s Integrated Risk Information System (IRIS) process. Washington, DC: The National Academies Press. 10.17226/18764.
NTP (National Toxicology Program). (2013). Draft OHAT approach for systematic review and evidence integration for literature-based health assessments – February 2013. National Institute of Environmental Health Sciences, National Institutes of Health. http://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/draftohatapproach_february2013.pdf.
NTP (National Toxicology Program). (2016). 14th Report on carcinogens. Research Triangle Park, NC. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html.
Nyanza, EC; Bernier, FP; Martin, JW; Manyama, M; Hatfield, J; Dewey, D. (2021). Effects of prenatal exposure and co-exposure to metallic or metalloid elements on early infant neurodevelopmental outcomes in areas with small-scale gold mining activities in Northern Tanzania. Environ Int 149: 106104. 10.1016/j.envint.2020.106104.32948351
Nyanza, EC; Dewey, D; Manyama, M; Martin, JW; Hatfield, J; Bernier, FP. (2020). Maternal exposure to arsenic and mercury and associated risk of adverse birth outcomes in small-scale gold mining communities in Northern Tanzania. Environ Int 137: 105450. 10.1016/j.envint.2019.105450.32014788
Ockene, IS; NH, M, iller. (1997). Cigarette smoking, cardiovascular disease, and stroke: A statement for healthcare professionals from the American Heart Association. Circulation 96: 3243–3247. 10.1161/01.CIR.96.9.3243.9386200
OEHHA (California Office of Environmental Health Hazard Assessment). (1996). Evidence on developmental and reproductive toxicity of inorganic arsenic. Sacramento, CA: California Environmental Protection Agency. https://oehha.ca.gov/media/downloads/proposition-65/chemicals/hid.pdf.
Osorio-Yáñez, C; Ayllon-Vergara, JC; Aguilar-Madrid, G; Arreola-Mendoza, L; Hernández-Castellanos, E; Barrera-Hernández, A; De Vizcaya-Ruiz, A; Del Razo, LM. (2013). Carotid intima-media thickness and plasma asymmetric dimethylarginine in Mexican children exposed to inorganic arsenic. Environ Health Perspect 121: 1090–1096. 10.1289/ehp.1205994.23757599
Osorio-Yáñez, C; Ayllon-Vergara, JC; Arreola-Mendoza, L; Aguilar-Madrid, G; Hernández-Castellanos, E; Sánchez-Peña, LC; Del Razo, LM. (2015). Blood pressure, left ventricular geometry, and systolic function in children exposed to inorganic arsenic. Environ Health Perspect 123: 629–635. 10.1289/ehp.1307327.25738397
Pacyna, JM. (1987). Atmospheric emissions of arsenic, cadmium, lead and mercury from high temperature processes in power generation and industry. In TC Hutchinson; KM Meema (Eds.), Lead, mercury, cadmium and arsenic in the environment (pp. 69–87). New York, NY: John Wiley & Sons. https://dge.carnegiescience.edu/SCOPE/SCOPE_31/SCOPE_31_2.02_Chapter7_69-87.pdf.
Pan, S; Lin, L; Zeng, F; Zhang, J; Dong, G; Yang, B; Jing, Y; Chen, S; Zhang, G; Yu, Z; Sheng, G; Ma, H. (2018). Effects of lead, cadmium, arsenic, and mercury co-exposure on children’s intelligence quotient in an industrialized area of southern China. Environ Pollut 235: 47–54. 10.1016/j.envpol.2017.12.044.29274537
Pan, TC; Lin, TH; Tseng, CL; Yang, MH; Huang, CW. (1993). Trace elements in hair of Blackfoot disease. Biol Trace Elem Res 39: 117–128. 10.1007/BF02783182.7509169
Pan, WC; Kile, ML; Seow, WJ; Lin, X; Quamruzzaman, Q; Rahman, M; Mahiuddin, G; Mostofa, G; Lu, Q; Christiani, DC. (2013a). Genetic susceptible locus in NOTCH2 interacts with arsenic in drinking water on risk of type 2 diabetes. PLoS ONE 8: e70792. 10.1371/journal.pone.0070792.23967108
Pan, WC; Seow, WJ; Kile, ML; Hoffman, EB; Quamruzzaman, Q; Rahman, M; Mahiuddin, G; Mostofa, G; Lu, Q; Christiani, DC. (2013b). Association of low to moderate levels of arsenic exposure with risk of type 2 diabetes in Bangladesh. Am J Epidemiol 178: 1563–1570. 10.1093/aje/kwt195.24049161
Papatheodorou, L; Weiss, N. (2007). Vascular oxidant stress and inflammation in hyperhomocysteinemia. Antioxid Redox Signal 9: 1941–1958. 10.1089/ars.2007.1750.17822365
Parajuli, RP; Fujiwara, T; Umezaki, M; Furusawa, H; Watanabe, C. (2014). Home environment and prenatal exposure to lead, arsenic and zinc on the neurodevelopment of six-month-old infants living in Chitwan Valley, Nepal. Neurotoxicol Teratol 41: 89–95. 10.1016/j.ntt.2013.12.006.24418190
Parajuli, RP; Fujiwara, T; Umezaki, M; Watanabe, C. (2015a). Home environment and cord blood levels of lead, arsenic, and zinc on neurodevelopment of 24 months children living in Chitwan Valley, Nepal. J Trace Elem Med Biol 29: 315–320. 10.1016/j.jtemb.2014.08.006.25213681
Parajuli, RP; Umezaki, M; Fujiwara, T; Watanabe, C. (2015b). Association of cord blood levels of lead, arsenic, and zinc and home environment with children neurodevelopment at 36 months living in Chitwan Valley, Nepal. PLoS ONE 10: e0120992. 10.1371/journal.pone.0120992.25803364
Park, SK; Peng, Q; Bielak, LF; Silver, KD; Peyser, PA; Mitchell, BD. (2015). Urinary arsenic and measures of insulin sensitivity and β-cell function in non-diabetic Amish adults. Diabetes - Metabolism: Research and Reviews (Online) 32: 565–571. 10.1002/dmrr.2769.
Parvez, F; Wasserman, GA; Factor-Litvak, P; Liu, X; Slavkovich, V; Siddique, AB; Sultana, R; Sultana, R; Islam, T; Levy, D; Mey, JL; van Geen, A; Khan, K; Kline, J; Ahsan, H; Graziano, JH. (2011). Arsenic exposure and motor function among children in Bangladesh. Environ Health Perspect 119: 1665–1670. 10.1289/ehp.1103548.21742576
Patti, MA; Kelsey, KT; Macfarlane, AJ; Papandonatos, GD; Arbuckle, T; Ashley-Martin, J; Fisher, M; Fraser, WD; Lanphear, BP; Muckle, G; Braun, JM. (2022). Maternal Folate Status and the Relation between Gestational Arsenic Exposure and Child Health Outcomes. Int J Environ Res Public Health 19. 10.3390/ijerph191811332.
Peng, Q; Harlow, SD; Park, SK. (2015a). Urinary arsenic and insulin resistance in US adolescents. Int J Hyg Environ Health 218: 407–413. 10.1016/j.ijheh.2015.03.006.25845984
Peng, SY; Liu, LP; Zhang, XQ; Heinrich, J; Zhang, J; Schramm, KW; Huang, QY; Tian, MP; Eqani, SAM, AS; Shen, HQ. (2015b). A nested case-control study indicating heavy metal residues in meconium associate with maternal gestational diabetes mellitus risk. Environ Health 14: 19. 10.1186/s12940-015-0004-0.25888735
Pi, J; Yamauchi, H; Sun, G; Yoshida, T; Aikawa, H; Fujimoto, W; Iso, H; Cui, R; Waalkes, MP; Kumagai, Y. (2005). Vascular dysfunction in patients with chronic arsenosis can be reversed by reduction of arsenic exposure. Environ Health Perspect 113: 339–341. 10.1289/ehp.7471.15743725
Pierce, BL; Kibriya, MG; Tong, L; Jasmine, F; Argos, M; Roy, S; Paul-Brutus, R; Rahaman, R; Rakibuz-Zaman, M; Parvez, F; Ahmed, A; Quasem, I; Hore, SK; Alam, S; Islam, T; Slavkovich, V; Gamble, MV; Yunus, M; Rahman, M; Baron, JA; Graziano, JH; Ahsan, H. (2012). Genome-wide association study identifies chromosome 10q24.32 variants associated with arsenic metabolism and toxicity phenotypes in bangladesh. PLoS Genet 8: e1002522. 10.1371/journal.pgen.1002522.22383894
Pogoson, E; Carey, M; Meharg, C; Meharg, AA. (2021). Reducing the cadmium, inorganic arsenic and dimethylarsinic acid content of rice through food-safe chemical cooking pre-treatment. Food Chem 338: 127842. 10.1016/j.foodchem.2020.127842.32822902
Pu, Y, -S; Yang, S, -M; Huang, Y, -K; Chung, C, -J; Huang, SK; Chiu, AW, -H; Yang, M, -H; Chen, C, -J; Hsueh, Y, -M. (2007). Urinary arsenic profile affects the risk of urothelial carcinoma even at low arsenic exposure. Toxicol Appl Pharmacol 218: 99–106. 10.1016/j.taap.2006.09.021.17196235
Rahbar, MH; Ibrahim, SH; Azam, SI; Hessabi, M; Karim, F; Kim, S; Zhang, J; Ali, NG; Loveland, KA. (2021). Concentrations of lead, mercury, arsenic, cadmium, manganese, and aluminum in the blood of Pakistani children with and without autism spectrum disorder and their associated factors. Int J Environ Res Public Health 18: 8625. 10.3390/ijerph18168625.34444373
Rahman, A; Persson, L, -Å; Nermell, B; El Arifeen, S; Ekström, E, -C; Smith, AH; Vahter, M. (2010). Arsenic exposure and risk of spontaneous abortion, stillbirth, and infant mortality. Epidemiology 21: 797–804. 10.1097/EDE.0b013e3181f56a0d.20864889
Rahman, A; Vahter, M; Ekström, E, -C; Persson, L, -Å. (2011). Arsenic exposure in pregnancy increases the risk of lower respiratory tract infection and diarrhea during infancy in Bangladesh. Environ Health Perspect 119: 719–724. 10.1289/ehp.1002265.21147604
Rahman, A; Vahter, M; Ekström, E, -C; Rahman, M; Golam Mustafa, AHM; Wahed, MA; Yunus, M; Persson, L, -Å. (2007). Association of arsenic exposure during pregnancy with fetal loss and infant death: A cohort study in Bangladesh. Am J Epidemiol 165: 1389–1396. 10.1093/aje/kwm025.17351293
Rahman, A; Vahter, M; Smith, AH; Nermell, B; Yunus, M; El Arifeen, S; Persson, L, -Å; Ekström, E, -C. (2009). Arsenic exposure during pregnancy and size at birth: A prospective cohort study in Bangladesh. Am J Epidemiol 169: 304–312. 10.1093/aje/kwn332.19037006
Rahman, M; Axelson, O. (2001). Arsenic ingestion and health effects in Bangladesh: Epidemiological observations. In WR Chappell; CO Abernathy; RL Calderon (Eds.), Arsenc Exposure and Health Effects IV (1 ed., pp. 193–199). Amsterdam, The Netherlands: Elsevier Science. https://books.google.com/books?id=kpT2eIxOCi8C&printsec=frontcover&source=gbs_ge_summary_r&cad=0#v=onepage&q&f=false.
Rahman, M; Sohel, N; Yunus, M; Chowdhury, ME; Hore, SK; Zaman, K; Bhuiya, A; Streatfield, PK. (2014). A prospective cohort study of stroke mortality and arsenic in drinking water in Bangladeshi adults. BMC Public Health 14: 174. 10.1186/1471-2458-14-174.24548416
Rahman, M; Tondel, M; Ahmad, SA; Chowdhury, IA; Faruquee, MH; Axelson, O. (1999). Hypertension and arsenic exposure in Bangladesh. Hypertension 33: 74–78. 10.1161/01.HYP.33.1.74.9931084
Rahman, ML; Kile, ML; Rodrigues, EG; Valeri, L; Raj, A; Mazumdar, M; Mostofa, G; Quamruzzaman, Q; Rahman, M; Hauser, R; Baccarelli, A; Liang, L; Christiani, DC. (2017a). Prenatal arsenic exposure, child marriage, and pregnancy weight gain: Associations with preterm birth in Bangladesh. Environ Int 112: 23–32. 10.1016/j.envint.2017.12.004.29245039
Rahman, ML; Oken, E; Hivert, MF; Rifas-Shiman, S; Lin, PID; Colicino, E; Wright, RO; Amarasiriwardena, C; Henn, BGC; Gold, DR; Coull, BA; Cardenas, A. (2021). Early pregnancy exposure to metal mixture and birth outcomes: A prospective study in Project Viva. Environ Int 156: 106714. 10.1016/j.envint.2021.106714.34147999
Rahman, ML; Valeri, L; Kile, ML; Mazumdar, M; Mostofa, G; Qamruzzaman, Q; Rahman, M; Baccarelli, A; Liang, L; Hauser, R; Christiani, DC. (2017b). Investigating causal relation between prenatal arsenic exposure and birthweight: Are smaller infants more susceptible? Environ Int 108: 32–40. 10.1016/j.envint.2017.07.026.28787626
Rangel-Moreno, K; Gamboa-Loira, B; López-Carrillo, L; Cebrián, ME. (2022). Prevalence of type 2 diabetes mellitus in relation to arsenic exposure and metabolism in Mexican women. Environ Res 210: 112948. 10.1016/j.envres.2022.112948.35189103
Remy, S; Govarts, E; Bruckers, L; Paulussen, M; Wens, B; Hond, ED; Nelen, V; Baeyens, W; van Larebeke, N; Loots, I; Sioen, I; Schoeters, G. (2014). Expression of the sFLT1 gene in cord blood cells is associated to maternal arsenic exposure and decreased birth weight. PLoS ONE 9: e92677. 10.1371/journal.pone.0092677.24664213
Ren, K; Li, X; Yan, J; Huang, G; Zhou, S; Yang, B; Ma, X; Lu, C. (2014). Knockdown of p66Shc by siRNA injection rescues arsenite-induced developmental retardation in mouse preimplantation embryos. Reprod Toxicol 43: 8–18. 10.1016/j.reprotox.2013.10.008.24184494
Renzetti, S; Cagna, G; Calza, S; Conversano, M; Fedrighi, C; Forte, G; Giorgino, A; Guazzetti, S; Majorani, C; Oppini, M; Peli, M; Petrucci, F; Pino, A; Placidi, D; Senofonte, O; Zoni, S; Alimonti, A; Lucchini, RG. (2021). The effects of the exposure to neurotoxic elements on Italian schoolchildren behavior. Sci Rep 11: 9898. 10.1038/s41598-021-88969-z.33972598
Reyes, L; Mañalich, R. (2005). Long-term consequences of low birth weight [Review]. Kidney Int Suppl 68: S107–S111. 10.1111/j.1523-1755.2005.09718.x.
Rezende, F; Moll, F; Walter, M; Helfinger, V; Hahner, F; Janetzko, P; Ringel, C; Weigert, A; Fleming, I; Weissmann, N; Kuenne, C; Looso, M; Rieger, MA; Nawroth, P; Fleming, T; Brandes, RP; Schröder, K. (2018). The NADPH organizers NoxO1 and p47phox are both mediators of diabetes-induced vascular dysfunction in mice. Redox Biology 15: 12–21. 10.1016/j.redox.2017.11.014.29195137
Rhee, SY; Hwang, YC; Woo, JT; Chin, SO; Chon, S; Kim, YS. (2013). Arsenic exposure and prevalence of diabetes mellitus in Korean adults. J Korean Med Sci 28: 861–868. 10.3346/jkms.2013.28.6.861.23772150
Rice, D; Barone, S, Jr. (2000). Critical periods of vulnerability for the developing nervous system: Evidence from humans and animal models [Review]. Environ Health Perspect 108: 511–533. 10.2307/3454543.10852851
Ríos, R; Zarazúa, S; Santoyo, ME; Sepúlveda-Saavedra, J; Romero-Díaz, V; Jiménez, V; Pérez-Severiano, F; Vidal-Cantú, G; Delgado, JM; Jiménez-Capdeville, ME. (2009). Decreased nitric oxide markers and morphological changes in the brain of arsenic-exposed rats. Toxicology 261: 68–75. 10.1016/j.tox.2009.04.055.19409443
Rocha-Amador, D; Navarro, ME; Carrizales, L; Morales, R; Calderón, J. (2007). Disminución de la inteligencia en niños y exposición al fl úor y arsénico en el agua potable. Cad Saude Publica 23: S579–S587. 10.1590/S0102-311X2007001600018.18038039
Rodrigues, EG; Bellinger, DC; Valeri, L; Hasan, MOS, I; Quamruzzaman, Q; Golam, M; Kile, ML; Christiani, DC; Wright, RO; Mazumdar, M. (2016). Neurodevelopmental outcomes among 2- to 3-year-old children in Bangladesh with elevated blood lead and exposure to arsenic and manganese in drinking water. Environ Health 15: 44. 10.1186/s12940-016-0127-y.26968381
Rodríguez-Barranco, M; Gil, F; Hernández, AF; Alguacil, J; Lorca, A; Mendoza, R; Gómez, I; Molina-Villalba, I; González-Alzaga, B; Aguilar-Garduño, C; Rohlman, DS; Lacasaña, M. (2016). Postnatal arsenic exposure and attention impairment in school children. Cortex 74: 370–382. 10.1016/j.cortex.2014.12.018.25682472
Rodríguez-Carrillo, A; Mustieles, V; D’Cruz, SC; Legoff, L; Gil, F; Olmedo, P; Reina-Pérez, I; Mundo, A; Molina, M; Smagulova, F; David, A; Freire, C; Fernández, MF. (2022). Exploring the relationship between metal exposure, BDNF, and behavior in adolescent males. Int J Hyg Environ Health 239: 113877. 10.1016/j.ijheh.2021.113877.34757248
Röllin, HB; Channa, K; Olutola, BG; Odland, JØ. (2016). Evaluation of in utero exposure to arsenic in South Africa. Sci Total Environ 575: 338–346. 10.1016/j.scitotenv.2016.10.044.27744161
Rosado, JL; Ronquillo, D; Kordas, K; Rojas, O; Alatorre, J; Lopez, P; Garcia-Vargas, G; del Caamaño, M, C; Cebrián, ME; Stoltzfus, RJ. (2007). Arsenic exposure and cognitive performance in Mexican schoolchildren. Environ Health Perspect 115: 1371–1375. 10.1289/ehp.9961.17805430
Ross, R. (1999). Atherosclerosis-an inflammatory disease. N Engl J Med 340: 115–126. 10.1056/NEJM199901143400207.9887164
Roy, A; Kordas, K; Lopez, P; Rosado, JL; Cebrian, ME; Garcia Vargas, G; Ronquillo, D; Stoltzfus, RJ. (2011). Association between arsenic exposure and behavior among first-graders from Torreón, Mexico. Environ Res 111: 670–676. 10.1016/j.envres.2011.03.003.21439564
Roy, R; Wilcox, J; Webb, AJ; O’Gallagher, K. (2023). Dysfunctional and dysregulated nitric oxide synthases in cardiovascular disease: Mechanisms and therapeutic potential [Review]. International Journal of Molecular Sciences 24. 10.3390/ijms242015200.
Ryan, PB; Huet, N; Macintosh, DL. (2000). Longitudinal investigation of exposure to arsenic, cadmium, and lead in drinking water. Environ Health Perspect 108: 731–735. 10.1289/ehp.00108731.10964793
Saha, KK; Engström, A; Hamadani, JD; Tofail, F; Rasmussen, KM; Vahter, M. (2012). Pre- and postnatal arsenic exposure and body size to two years of age: A cohort study in rural Bangladesh. Environ Health Perspect 120: 1208–1214. 10.1289/ehp.1003378.22504586
Saint-Jacques, N; Parker, L; Brown, P; Dummer, TJB. (2014). Arsenic in drinking water and urinary tract cancers: A systematic review of 30 years of epidemiological evidence [Review]. Environ Health 13: 44. 10.1186/1476-069X-13-44.24889821
Salihu, HM; Wilson, RE. (2007). Epidemiology of prenatal smoking and perinatal outcomes [Review]. Early Hum Dev 83: 713–720. 10.1016/j.earlhumdev.2007.08.002.17884310
Sams, R, II; Wolf, DC; Ramasamy, S; Ohanian, E; Chen, J; Lowit, A. (2007). Workshop overview: Arsenic research and risk assessment. Toxicol Appl Pharmacol 222: 245–251. 10.1016/j.taap.2007.01.007.17336359
Sánchez-Peña, LC; Petrosyan, P; Morales, M; González, NB; Gutiérrez-Ospina, G; Del Razo, LM; Gonsebatt, ME. (2010). Arsenic species, AS3MT amount, and AS3MT gene expression in different brain regions of mouse exposed to arsenite. Environ Res 110: 428–434. 10.1016/j.envres.2010.01.007.20138265
Sasco, AJ; Secretan, MB; Straif, K. (2004). Tobacco smoking and cancer: A brief review of recent epidemiological evidence [Review]. Lung Cancer 45(Suppl. 2): S3–S9. 10.1016/j.lungcan.2004.07.998.
Saxena, R; Gamble, M; Wasserman, GA; Liu, X; Parvez, F; Navas-Acien, A; Islam, T; Factor-Litvak, P; Uddin, MN; Kioumourtzoglou, MA; Gibson, EA; Shahriar, H; Slavkovich, V; Ilievski, V; Loiacono, N; Balac, O; Graziano, JH. (2022). Mixed metals exposure and cognitive function in Bangladeshi adolescents. Ecotoxicol Environ Saf 232: 113229. 10.1016/j.ecoenv.2022.113229.35131582
Schwarzenbach, RP; Egli, T; Hofstetter, TB; Von Gunten, U; Wehrli, B. (2010). Global Water Pollution and Human Health. Annu Rev Environ Resour 35: 109–136. 10.1146/annurev-environ-100809-125342.
Shakya, A; Dodson, M; Artiola, J; Ramirez-Andreotta, M; Root, R; Ding, X; Chorover, J; Maier, R. (2023). Arsenic in Drinking Water and Diabetes. Water 15. 10.3390/w15091751.
Shao, K; Zhou, Z; Xun, P; Cohen, SM. (2021). Bayesian benchmark dose analysis for inorganic arsenic in drinking water associated with bladder and lung cancer using epidemiological data. Toxicology 455: 152752. 10.1016/j.tox.2021.152752.33741492
Shapiro, GD; Dodds, L; Arbuckle, TE; Ashley-Martin, J; Fraser, W; Fisher, M; Taback, S; Keely, E; Bouchard, MF; Monnier, P; Dallaire, R; Morisset, AS; Ettinger, AS. (2015). Exposure to phthalates, bisphenol A and metals in pregnancy and the association with impaired glucose tolerance and gestational diabetes mellitus: The MIREC study. Environ Int 83: 63–71. 10.1016/j.envint.2015.05.016.26101084
Shibata, T; Meng, C; Umoren, J; West, H. (2016). Risk Assessment of Arsenic in Rice Cereal and Other Dietary Sources for Infants and Toddlers in the U.S. Int J Environ Res Public Health 13: 361. 10.3390/ijerph13040361.27023581
Shih, YH; Bryan, MS; Argos, M. (2020). Association between prenatal arsenic exposure, birth outcomes, and pregnancy complications: An observational study within the National Children’s Study cohort. Environ Res 183: 109182. 10.1016/j.envres.2020.109182.32058141
Shih, YH; Islam, T; Hore, SK; Sarwar, G; Shahriar, MH; Yunus, M; Graziano, JH; Harjes, J; Baron, JA; Parvez, F; Ahsan, H; Argos, M. (2017). Associations between prenatal arsenic exposure with adverse pregnancy outcome and child mortality. Environ Res 158: 456–461. 10.1016/j.envres.2017.07.004.28692928
Sidhu, MS; Desai, KP; Lynch, HN; Rhomberg, LR; Beck, BD; Venditti, FJ. (2015). Mechanisms of action for arsenic in cardiovascular toxicity and implications for risk assessment [Review]. Toxicology 331: 78–99. 10.1016/j.tox.2015.02.008.25771173
Signes-Pastor, AJ; Carey, M; Meharg, AA. (2016). Inorganic arsenic in rice-based products for infants and young children. Food Chem 191: 128–134. 10.1016/j.foodchem.2014.11.078.26258711
Signes-Pastor, AJ; Cottingham, KL; Carey, M; Sayarath, V; Palys, T; Meharg, AA; Folt, CL; Karagas, MR. (2018). Infants’ dietary arsenic exposure during transition to solid food. Sci Rep 8: 7114. 10.1038/s41598-018-25372-1.29739998
Signes-Pastor, AJ; Doherty, BT; Romano, ME; Gleason, KM; Gui, J; Baker, E; Karagas, MR. (2019a). Prenatal exposure to metal mixture and sex-specific birth outcomes in the New Hampshire Birth Cohort Study. Environmental Epidemiology 3: e068. 10.1097/EE9.0000000000000068.31844832
Signes-Pastor, AJ; Romano, ME; Jackson, B; Braun, JM; Yolton, K; Chen, A; Lanphear, B; Karagas, MR. (2022). Associations of maternal urinary arsenic concentrations during pregnancy with childhood cognitive abilities: The HOME study. Int J Hyg Environ Health 245: 114009. 10.1016/j.ijheh.2022.114009.35947921
Signes-Pastor, AJ; Vioque, J; Navarrete-Muñoz, EM; Carey, M; García-Villarino, M; Fernández-Somoano, A; Tardón, A; Santa-Marina, L; Irizar, A; Casas, M; Guxens, M; Llop, S; Soler-Blasco, R; García-de-la-Hera, M; Karagas, MR; Meharg, AA. (2019b). Inorganic arsenic exposure and neuropsychological development of children of 4-5 years of age living in Spain. Environ Res 174: 135–142. 10.1016/j.envres.2019.04.028.31075694
Simeonova, PP; Hulderman, T; Harki, D; Luster, MI. (2003). Arsenic exposure accelerates atherogenesis in apolipoprotein E(-/-) mice. Environ Health Perspect 111: 1744–1748. 10.1289/ehp.6332.14594625
Simić, A; Hansen, AF; Åsvold, BO; Romundstad, PR; Midthjell, K; Syversen, T; Flaten, TP. (2017). Trace element status in patients with type 2 diabetes in Norway: The HUNT3 Survey. J Trace Elem Med Biol 41: 91–98. 10.1016/j.jtemb.2017.03.001.28347468
Singh, S; Greene, RM; Pisano, MM. (2010). Arsenate-induced apoptosis in murine embryonic maxillary mesenchymal cells via mitochondrial-mediated oxidative injury. Birth Defects Res A Clin Mol Teratol 88: 25–34. 10.1002/bdra.20623.19739150
Singh, V; Kaur, R; Kumari, P; Pasricha, C; Singh, R. (2023). ICAM-1 and VCAM-1: Gatekeepers in various inflammatory and cardiovascular disorders. Clin Chim Acta 548: 117487. 10.1016/j.cca.2023.117487.37442359
Skogheim, TS; Weyde, KVF; Engel, SM; Aase, H; Surén, P; Øie, MG; Biele, G; Reichborn-Kjennerud, T; Caspersen, IH; Hornig, M; Haug, LS; Villanger, GD. (2021). Metal and essential element concentrations during pregnancy and associations with autism spectrum disorder and attention-deficit/hyperactivity disorder in children. Environ Int 152: 106468. 10.1016/j.envint.2021.106468.33765546
Skröder, H; Hawkesworth, S; Kippler, M; El Arifeen, S; Wagatsuma, Y; Moore, SE; Vahter, M. (2015). Kidney function and blood pressure in preschool-aged children exposed to cadmium and arsenic - potential alleviation by selenium. Environ Res 140: 205–213. 10.1016/j.envres.2015.03.038.25863594
Smith, AH; Marshall, G; Liaw, J; Yuan, Y; Ferreccio, C; Steinmaus, C. (2012). Mortality in young adults following in utero and childhood exposure to arsenic in drinking water. Environ Health Perspect 120: 1527–1531. 10.1289/ehp.1104867.22949133
Smith, KR; Klei, LR; Barchowsky, A. (2001). Arsenite stimulates plasma membrane NADPH oxidase in vascular endothelial cells. Am J Physiol Lung Cell Mol Physiol 280: L422–L449. 10.1152/ajplung.2001.280.3.L442.
Snow, ET; Sykora, P; Durham, TR; Klein, CB. (2005). Arsenic, mode of action at biologically plausible low doses: What are the implications for low dose cancer risk? [Review]. Toxicol Appl Pharmacol 207: S557–S564. 10.1016/j.taap.2005.01.048.
Sohel, N; Persson, LÅ; Rahman, M; Streatfield, PK; Yunus, M; Ekström, E, -C; Vahter, M. (2009). Arsenic in drinking water and adult mortality: A population-based cohort study in rural Bangladesh. Epidemiology 20: 824–830. 10.1097/EDE.0b013e3181bb56ec.19797964
Soler-Blasco, R; Murcia, M; Lozano, M; Sarzo, B; Esplugues, A; Riutort-Mayol, G; Vioque, J; Lertxundi, N; Santa Marina, L; Lertxundi, A; Irizar, A; Braeuer, S; Ballester, F; Llop, S. (2022). Prenatal arsenic exposure, arsenic methylation efficiency, and neuropsychological development among preschool children in a Spanish birth cohort. Environ Res 207: 112208. 10.1016/j.envres.2021.112208.34662579
Solti, F; Szatmáry, L; Vecsey, T; Szabolcs, Z. (1989). The effect of sympathetic and parasympathetic activity on QT duration. Clinical study in patients with normal and prolonged QT time. Cor VASA 31: 9–15.2721207
Soucy, NV; Ihnat, MA; Kamat, CD; Hess, L; Post, MJ; Klei, LR; Clark, C; Barchowsky, A. (2003). Arsenic stimulates angiogenesis and tumorigenesis in vivo. Toxicol Sci 76: 271–279. 10.1093/toxsci/kfg231.12970581
Soucy, NV; Mayka, D; Klei, LR; Nemec, AA; Bauer, JA; Barchowsky, A. (2005). Neovascularization and angiogenic gene expression following chronic arsenic exposure in mice. Cardiovasc Toxicol 5: 29–41. 10.1385/ct:5:1:029.15738583
Spratlen, MJ; Grau-Perez, M; Best, LG; Yracheta, J; Lazo, M; Vaidya, D; Balakrishnan, P; Gamble, MV; Francesconi, KA; Goessler, W; Cole, SA; Umans, JG; Howard, BV; Navas-Acien, A. (2018). The association of arsenic exposure and arsenic metabolism with the metabolic syndrome and its individual components: Prospective evidence from the strong heart family study. Am J Epidemiol 187: 1598–1612. 10.1093/aje/kwy048.29554222
Srivastava, S; D’Souza, SE; Sen, U; States, JC. (2007). In utero arsenic exposure induces early onset of atherosclerosis in ApoE-/- mice. Reprod Toxicol 23: 449–456. 10.1016/j.reprotox.2007.01.005.17317095
Srivastava, S; Vladykovskaya, EN; Haberzettl, P; Sithu, SD; D’Souza, SE; States, JC. (2009). Arsenic exacerbates atherosclerotic lesion formation and inflammation in ApoE-/- mice. Toxicol Appl Pharmacol 241: 90–100. 10.1016/j.taap.2009.08.004.19682479
Stea, F; Faita, F; Borghini, A; Faita, F; Bianchi, F; Bustaffa, E; Minichilli, F; Andreassi, MG; Sicari, R. (2016). Arsenic and subclinical vascular damage in a sample of Italian young adults: a cross-sectional analysis. Environ Sci Pollut Res Int 23: 20307–20314. 10.1007/s11356-016-7260-6.27448814
Stein, CR; Wu, H; Bellinger, DC; Smith, DR; Wolff, MS; Savitz, DA. (2022). Exposure to metal mixtures and neuropsychological functioning in middle childhood. Neurotoxicology 93: 84–91. 10.1016/j.neuro.2022.09.003.36122627
Steinmaus, C; Castriota, F; Ferreccio, C; Smith, AH; Yuan, Y; Liaw, J; Acevedo, J; Pérez, L; Meza, R; Calcagno, S; Uauy, R; Smith, MT. (2015). Obesity and excess weight in early adulthood and high risks of arsenic-related cancer in later life. Environ Res 142: 594–601. 10.1016/j.envres.2015.07.021.26301739
Steinmaus, C; Ferreccio, C; Acevedo, J; Yuan, Y; Liaw, J; Durán, V; Cuevas, S; García, J; Meza, R; Valdés, R; Valdés, G; Benítez, H; Vanderlinde, V; Villagra, V; Cantor, KP; Moore, LE; Perez, SG; Steinmaus, S; Smith, AH. (2014a). Increased lung and bladder cancer incidence in adults after in utero and early-life arsenic exposure. Cancer Epidemiol Biomarkers Prev 23: 1529–1538. 10.1158/1055-9965.EPI-14-0059.24859871
Steinmaus, C; Ferreccio, C; Yuan, Y; Acevedo, J; González, F; Perez, L; Cortés, S; Balmes, JR; Liaw, J; Smith, AH. (2014b). Elevated lung cancer in younger adults and low concentrations of arsenic in water. Am J Epidemiol 180: 1082–1087. 10.1093/aje/kwu238.25371173
Steinmaus, C; Yuan, Y; Bates, MN; Smith, AH. (2003). Case-control study of bladder cancer and drinking water arsenic in the western United States. Am J Epidemiol 158: 1193–1201. 10.1093/aje/kwg281.14652304
Steinmaus, C; Yuan, Y; Liaw, J; Smith, AH. (2009). Low-level population exposure to inorganic arsenic in the United States and diabetes mellitus: A reanalysis. Epidemiology 20: 807–815. 10.1097/EDE.0b013e3181b0fd29.19652600
Steinmaus, CM; Ferreccio, C; Romo, JA; Yuan, Y; Cortes, S; Marshall, G; Moore, LE; Balmes, JR; Liaw, J; Golden, T; Smith, AH. (2013). Drinking water arsenic in northern Chile: High cancer risks 40 years after exposure cessation. Cancer Epidemiol Biomarkers Prev 22: 623–630. 10.1158/1055-9965.EPI-12-1190.23355602
Steinmaus, CM; Yuan, Y; Smith, AH. (2005). The temporal stability of arsenic concentrations in well water in western Nevada. Environ Res 99: 164–168. 10.1016/j.envres.2004.10.003.16194666
Straub, AC; Clark, KA; Ross, MA; Chandra, AG; Li, S; Gao, X; Pagano, PJ; Stolz, DB; Barchowsky, A. (2008). Arsenic-stimulated liver sinusoidal capillarization in mice requires NADPH oxidase-generated superoxide. J Clin Invest 118: 3980–3989. 10.1172/JCI35092.19033667
Su, C, -T; Lin, H, -C; Choy, C, -S; Huang, Y, -K; Huang, S, -R; Hsueh, Y, -M. (2012). The relationship between obesity, insulin and arsenic methylation capability in Taiwan adolescents. Sci Total Environ 414: 152–158. 10.1016/j.scitotenv.2011.10.023.22104380
Sun, X; Zhou, X; Du, L; Liu, W; Liu, Y; Hudson, LG; Liu, KJ. (2014). Arsenite binding-induced zinc loss from PARP-1 is equivalent to zinc deficiency in reducing PARP-1 activity, leading to inhibition of DNA repair. Toxicol Appl Pharmacol 274: 313–318. 10.1016/j.taap.2013.11.010.24275069
Sun, XJ; Liu, WY; Zhang, B; Shen, XT; Hu, C; Chen, XM; Jin, SN; Jiang, YQ; Liu, HX; Cao, ZQ; Xia, W; Xu, SQ; Li, YY. (2019). Maternal heavy metal exposure, thyroid hormones, and birth outcomes: A prospective cohort study. J Clin Endocrinol Metab 104: 5043–5052. 10.1210/jc.2018-02492.30994896
TCEQ (Texas Commission on Environmental Quality). (2017). Inorganic arsenic oral slope factor. Developmental support document. Proposed, August 16 2017.
Thomas, S; Arbuckle, TE; Fisher, M; Fraser, WD; Ettinger, A; King, W. (2015). Metals exposure and risk of small-for-gestational age birth in a Canadian birth cohort: The MIREC study. Environ Res 140: 430–439. 10.1016/j.envres.2015.04.018.25967284
Tian, M, .; Reichetzeder, C, .; Li, J, .; Hocher, B, . (2019). Low birth weight, a risk factor for diseases in later life, is a surrogate of insulin resistance at birth. J Hypertens 37: 2123–2134. 10.1097/HJH.0000000000002156.31157747
Tofail, F; Vahter, M; Hamadani, JD; Nermell, B; Huda, SN; Yunus, M; Rahman, M; Grantham-Mcgregor, SM. (2009). Effect of arsenic exposure during pregnancy on infant development at 7 months in rural Matlab, Bangladesh. Environ Health Perspect 117: 288–293. 10.1289/ehp.11670.19270801
Tollestrup, K; Frost, FJ; Harter, LC; Mcmillan, A. (2003). Mortality among children residing near the American Smelting and Refining Company (ASARCO) copper smelter in Ruston, Washington. Arch Environ Health 58: 683–691. 10.3200/AEOH.58.11.683-691.15702892
Tsai, S, -M; Wang, T, -N; Ko, Y, -C. (1999). Mortality for certain diseases in areas with high levels of arsenic in drinking water. Arch Environ Health 54: 186–193. 10.1080/00039899909602258.10444040
Tseng, C, -H; Chong, C, -K; Chen, C, -J; Tai, T, -Y. (1996). Dose-response relationship between peripheral vascular disease and ingested inorganic arsenic among residents in Blackfoot disease endemic villages in Taiwan. Atherosclerosis 120: 125–133. 10.1016/0021-9150(95)05693-9.8645353
Tseng, C, -H; Chong, C, -K; Chen, C, -J; Tai, T, -Y. (1997). Lipid profile and peripheral vascular disease in arseniasis-hyperendemic villages in Taiwan. Angiology 48: 321–335. 10.1177/000331979704800405.9112880
Tseng, C, -H; Chong, C, -K; Tseng, C, -P; Hsueh, Y, -M; Chiou, H, -Y; Tseng, C, -C; Chen, C, -J. (2003). Long-term arsenic exposure and ischemic heart disease in arseniasis-hyperendemic villages in Taiwan. Toxicol Lett 137: 15–21. 10.1016/S0378-4274(02)00377-6.12505429
Tseng, C, -H; Huang, Y, -K; Huang, Y, -L; Chung, C, -J; Yang, M, -H; Chen, C, -J; Hsueh, Y, -M. (2005). Arsenic exposure, urinary arsenic speciation, and peripheral vascular disease in Blackfoot disease-hyperendemic villages in Taiwan. Toxicol Appl Pharmacol 206: 299–308. 10.1016/j.taap.2004.11.022.16039941
Tseng, C, -H; Tai, T, -Y; Chong, C, -K; Tseng, C, -P; Lai, M, -S; Lin, BJ; Chiou, H, -Y; Hsueh, Y, -M; Hsu, K, -H; Chen, C, -J. (2000). Long-term arsenic exposure and incidence of non-insulin-dependent diabetes mellitus: A cohort study in arseniasis-hyperendemic villages in Taiwan. Environ Health Perspect 108: 847–851. 10.1289/ehp.00108847.11017889
Tseng, CH. (2002). An overview on peripheral vascular disease in blackfoot disease-hyperendemic villages in Taiwan [Review]. Angiology 53: 529–537. 10.1177/000331970205300505.12365859
Tseng, W, -P; Chu, H, -M; How, S, -W; Fong, J, -M; Lin, C, -S; Yeh, S. (1968). Prevalence of skin cancer in an endemic area of chronic arsenicism in Taiwan. J Natl Cancer Inst 40: 453–463. 10.1093/jnci/40.3.453.5644201
Tseng, WP. (1977). Effects and dose-response relationships of skin cancer and Blackfoot disease with arsenic. Environ Health Perspect 19: 109–119.908285
Tsinovoi, CL; Xun, P; Mcclure, LA; Carioni, VMO; Brockman, JD; Cai, J; Guallar, E; Cushman, M; Unverzagt, FW; Howard, VJ; He, K. (2018). Arsenic exposure in relation to ischemic stroke: The reasons for geographic and racial differences in stroke study. Stroke 49: 19–26. 10.1161/STROKEAHA.117.018891.29212736
U.S. EPA (U.S. Environmental Protection Agency). (1982). An exposure and risk assessment for arsenic [EPA Report]. (EPA 440/4-85-005). Washington, DC: US Environmental Protection Agency, Office of Water. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB85221711.xhtml.
U.S. EPA (U.S. Environmental Protection Agency). (1986). Guidelines for carcinogen risk assessment [EPA Report] (pp. 33993–34003). (EPA/630/R-00/004). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://cfpub.epa.gov/ncea/raf/car2sab/guidelines_1986.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (1993). Toxicological review of inorganic arsenic [EPA Report]. Washington, DC. http://www.epa.gov/NCEA/iris/subst/0278.htm.
U.S. EPA (U.S. Environmental Protection Agency). (1994). Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry [EPA Report]. (EPA600890066F). Research Triangle Park, NC. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=71993&CFID=51174829&CFTOKEN=25006317.
U.S. EPA (U.S. Environmental Protection Agency). (1995). Integrated Risk Information System (IRIS) on arsenic, inorganic [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0278_summary.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2002a). Implementation guidance for the arsenic rule: Drinking water regulations for arsenic and clarifications to compliance and new source contaminants monitoring [EPA Report]. (EPA-816-K-02-018). Washington, DC. https://nepis.epa.gov/Exe/ZyPDF.cgi?Dockey=P1009V6R.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2002b). A review of the reference dose and reference concentration processes [EPA Report]. (EPA630P02002F). Washington, DC. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2005a). Guidelines for carcinogen risk assessment [EPA Report]. (EPA630P03001F). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3-25-05.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2005b). Supplemental guidance for assessing susceptibility from early-life exposure to carcinogens [EPA Report]. (EPA/630/R-03/003F). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/supplemental-guidance-assessing-susceptibility-early-life-exposure-carcinogens.
U.S. EPA (U.S. Environmental Protection Agency). (2006). Revised re-registration eligibility decision document for MSMA, DSMA, CAMA, and cacodylic acid [EPA Report]. (EPA/738-R-06-021). Washington, DC.
U.S. EPA (U.S. Environmental Protection Agency). (2010). Toxicological review of Chloroprene (CASRN 126-99-8) in support of summary information on the Integrated Risk Information System (IRIS) [EPA Report]. (EPA/635/R-09/010F). Washington, DC. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P1008LW6.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2011). Exposure Factors Handbook, Chapter 8: Body weight studies. Washington, DC. https://www.epa.gov/expobox/exposure-factors-handbook-chapter-8.
U.S. EPA (U.S. Environmental Protection Agency). (2012). Benchmark dose technical guidance [EPA Report]. (EPA100R12001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/benchmark-dose-technical-guidance.
U.S. EPA (U.S. Environmental Protection Agency). (2019). Exposure factors handbook chapter 3 (update): Ingestion of water and other select liquids [EPA Report]. (EPA/600/R-18/259F). Washington, DC. https://cfpub.epa.gov/ncea/efp/recordisplay.cfm?deid=343661.
U.S. EPA (U.S. Environmental Protection Agency). (2020). ORD staff handbook for developing IRIS assessments (public comment draft) [EPA Report]. (EPA600R20137). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Center for Public Health and Environmental Assessment. https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=350086.
U.S. EPA (U.S. Environmental Protection Agency). (2022). ORD staff handbook for developing IRIS assessments. (EPA 600/R-22/268). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Center for Public Health and Environmental Assessment. https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=356370.
U.S. EPA (U.S. Environmental Protection Agency). (2024a). Toxicological review of perfluorodecanoic acid (PFDA) and related salts (Final report, 2024). (EPA/635/R-24/172Fa). Washington, DC. https://iris.epa.gov/document/&deid=361797?
U.S. EPA (U.S. Environmental Protection Agency). (2024b). Workflow and modeling results and variable dictionary- Nov 21 2024 [EPA Report]. Washington, DC.
U.S. EPA (U.S. Environmental Protection Agency). (2025). Arsenic Dose-Response Modeling Results – January 2025. Retrieved from https://gaftp.epa.gov/CPHEA/Inorganic%20Arsenic%20Dose-Response%20Modeling%20Results%20%e2%80%93%20January%202025/
Vahter, M. (1994). Species differences in the metabolism of arsenic compounds. Applied Organometallic Chemistry 8: 175–182. 10.1002/aoc.590080304.
Vahter, M. (2009). Effects of arsenic on maternal and fetal health [Review]. Annu Rev Nutr 29: 381–399. 10.1146/annurev-nutr-080508-141102.19575603
Vahter, M; Concha, G. (2001). Role of metabolism in arsenic toxicity [Review]. Pharmacol Toxicol 89: 1–5. 10.1034/j.1600-0773.2001.d01-128.x.
Vahter, M; Norin, H. (1980). Metabolism of 74As-labeled trivalent and pentavalent inorganic arsenic in mice. Environ Res 21: 446–457. 10.1016/0013-9351(80)90049-3.7408817
Vahter, M; Skröder, H; Rahman, SM; Levi, M; Hamadani, JD; Kippler, M. (2020). Prenatal and childhood arsenic exposure through drinking water and food and cognitive abilities at 10 years of age: A prospective cohort study. Environ Int 139: 105723. 10.1016/j.envint.2020.105723.32298878
Vaidya, N; Holla, B; Heron, J; Sharma, E; Zhang, Y; Fernandes, G; Iyengar, U; Spiers, A; Yadav, A; Das, S; Roy, S; Ahuja, CK; Barker, GJ; Basu, D; Bharath, RD; Hickman, M; Jain, S; Kalyanram, K; Kartik, K; Krishna, M; Krishnaveni, G; Kumaran, K; Kuriyan, R; Murthy, P; Papadopoulos Orfanos, D; Purushottam, M; Kurpad, SS; Singh, L; Singh, R; Subodh, BN; Toledano, M; Walter, H; Desrivières, S; Chakrabarti, A; Benegal, V; Schumann, G; (cVEDA), CoVtEDaA. (2023). Neurocognitive Analysis of Low-level Arsenic Exposure and Executive Function Mediated by Brain Anomalies Among Children, Adolescents, and Young Adults in India. JAMA Netw Open 6: e2312810. 10.1001/jamanetworkopen.2023.12810.37171822
Veeraraghavan, R; Parinandi, NL; Hund, TJ. (2020). Oxidant-induced models of vascular leak. In LJ Berliner; NL Parinandi (Eds.), Measuring Oxidants and Oxidative Stress in Biological Systems. New York, NY: Springer. 10.1007/978-3-030-47318-1_6.
Velmurugan, G; Swaminathan, K; Veerasekar, G; Purnell, JQ; Mohanraj, S; Dhivakar, M; Avula, AK; Cherian, M; Palaniswami, NG; Alexander, T; Pradeep, T. (2018). Metals in urine in relation to the prevalence of pre-diabetes, diabetes and atherosclerosis in rural India. Occup Environ Med 75: 661–667. 10.1136/oemed-2018-104996.29674487
Vibol, S; Hashim, JH; Sarmani, S. (2015). Neurobehavioral effects of arsenic exposure among secondary school children in the Kandal Province, Cambodia. Environ Res 137C: 329–337. 10.1016/j.envres.2014.12.001.
von Ehrenstein, OS; Guha Mazumder, DN; Hira-Smith, M; Ghosh, N; Yuan, Y; Windham, G; Ghosh, A; Haque, R; Lahiri, S; Kalman, D; Das, S; Smith, AH. (2006). Pregnancy outcomes, infant mortality, and arsenic in drinking water in West Bengal, India. Am J Epidemiol 163: 662–669. 10.1093/aje/kwj089.16524957
von Ehrenstein, OS; Poddar, S; Yuan, Y; Guha Mazumder, D; Eskenazi, B; Basu, A; Hira-Smith, M; Ghosh, N; Lahiri, S; Haque, R; Ghosh, A; Kalman, D; Das, S; Smith, AH. (2007). Children’s intellectual function in relation to arsenic exposure. Epidemiology 18: 44–51. 10.1097/01.ede.0000248900.65613.a9.17149142
Wade, TJ; Xia, Y; Mumford, J; Wu, K; Le, XC; Sams, E; Sanders, WE. (2015). Cardiovascular disease and arsenic exposure in Inner Mongolia, China: a case control study. Environ Health 14: 35. 10.1186/s12940-015-0022-y.25889926
Wade, TJ; Xia, Y; Wu, K; Li, Y; Ning, Z; Le, XC; Lu, X; Feng, Y; He, X; Mumford, JL. (2009). Increased mortality associated with well-water arsenic exposure in Inner Mongolia, China. Int J Environ Res Public Health 6: 1107–1123. 10.3390/ijerph6031107.19440436
Wai, K, aM; Wu, S; Li, X; Jaffe, DA; Perry, KD. (2016). Global Atmospheric Transport and Source-Receptor Relationships for Arsenic. Environ Sci Technol 50: 3714–3720. 10.1021/acs.est.5b05549.26906891
Wai, KM; Mar, O; Kosaka, S; Umemura, M; Watanabe, C. (2017). Prenatal heavy metal exposure and adverse birth outcomes in myanmar: a birth-cohort study. Int J Environ Res Public Health 14. 10.3390/ijerph14111339.
Wai, KM; Ser, PH; Ahmad, SA; Yasmin, R; Ito, Y; Konishi, S; Umezaki, M; Watanabe, C. (2020). In-utero arsenic exposure and growth of infants from birth to 6 months of age: A prospective cohort study in rural Bangladesh. Int J Environ Health Res 30: 421–434. 10.1080/09603123.2019.1597835.30924685
Wang, C, -H; Chen, C, -L; Hsiao, CK; Chiang, F, -T; Hsu, L, -I; Chiou, H, -Y; Hsueh, Y, -M; Wu, M, -M; Chen, C, -J. (2009). Increased risk of QT prolongation associated with atherosclerotic diseases in arseniasis-endemic area in southwestern coast of Taiwan. Toxicol Appl Pharmacol 239: 320–324. 10.1016/j.taap.2009.06.017.19573547
Wang, C, -H; Chen, C, -L; Hsiao, CK; Chiang, F, -T; Hsu, L, -I; Chiou, H, -Y; Hsueh, Y, -M; Wu, M, -M; Chen, C, -J. (2010). Arsenic-induced QT dispersion is associated with atherosclerotic diseases and predicts long-term cardiovascular mortality in subjects with previous exposure to arsenic: A 17-Year follow-up study. Cardiovasc Toxicol 10: 17–26. 10.1007/s12012-009-9059x.19957052
Wang, C, -H; Jeng, J, -S; Yip, P, -K; Chen, C, -L; Hsu, L, -I; Hsueh, Y, -M; Chiou, H, -Y; Wu, M, -M; Chen, C, J. (2002). Biological gradient between long-term arsenic exposure and carotid atherosclerosis. Circulation 105: 1804–1809. 10.1161/01.CIR.0000015862.64816.B2.11956123
Wang, S, -X; Wang, Z, -H; Cheng, X, -T; Li, J; Sang, Z, -P; Zhang, X, -D; Han, L, -L; Qiao, X, -Y; Wu, Z, -M; Wang, Z, -Q. (2006). Arsenic and fluoride exposure in drinking water: Children’s IQ and growth in Shanyin county, Shanxi province, China. Environ Health Perspect 115: 643–647. 10.1289/ehp.9270.
Wang, SL; Chang, FH; Liou, SH; Wang, YC; Feng, BJ. (2005). Arsenic dose and its relation to cardiovascular risk among residents in middle Taiwan. Epidemiology 16: S25–S25.
Wang, SL; Li, WF; Chen, CJ; Huang, YL; Chen, JW; Chang, KH; Tsai, LY; Chou, KM. (2011). Hypertension incidence after tap-water implementation: A 13-year follow-up study in the arseniasis-endemic area of southwestern Taiwan. Sci Total Environ 409: 4528–4535. 10.1016/j.scitotenv.2011.07.058.21872294
Wang, W; Xie, Z; Lin, Y; Zhang, D. (2014). Association of inorganic arsenic exposure with type 2 diabetes mellitus: A meta-analysis [Review]. J Epidemiol Community Health 68: 176–184. 10.1136/jech-2013-203114.24133074
Wang, Y, -H; Wu, M, -M; Hong, C, -T; Lien, L, -M; Hsieh, Y, -C; Tseng, H, -P; Chang, S, -F; Su, C, -L; Chiou, H, -Y; Chen, C, -J. (2007). Effects of arsenic exposure and genetic polymorphisms of p53, glutathione S-transferase M1, T1, and P1 on the risk of carotid atherosclerosis in Taiwan. Atherosclerosis 192: 305–312. 10.1016/j.atherosclerosis.2006.07.029.16973168
Wang, Y; Wang, S; Wang, Y; Lu, A; Cao, L; Wang, J; Gao, Z; Yan, C. (2022a). Effects of prenatal exposure to arsenic on neonatal birth size in Wujiang, China. Chemosphere 299: 134441. 10.1016/j.chemosphere.2022.134441.35358562
Wang, Y; Wang, Y; Yan, C. (2022b). Gender differences in trace element exposures with cognitive abilities of school-aged children: A cohort study in Wujiang City, China. Environ Sci Pollut Res Int 29: 64807–64821. 10.1007/s11356-022-20353-4.35474433
Wasserman, GA; Liu, X; Loiacono, NJ; Kline, J; Factor-Litvak, P; van Geen, A; Mey, JL; Levy, D; Abramson, R; Schwartz, A; Graziano, JH. (2014). A cross-sectional study of well water arsenic and child IQ in Maine schoolchildren. Environ Health 13: 23. 10.1186/1476-069X-13-23.24684736
Wasserman, GA; Liu, X; Parvez, F; Ahsan, H; Factor-Litvak, P; Kline, J; van Geen, A; Slavkovich, V; Lolacono, NJ; Levy, D; Cheng, ZQ; Graziano, JH. (2007). Water arsenic exposure and intellectual function in 6-year-old children in Araihazar, Bangladesh. Environ Health Perspect 115: 285–289. 10.1289/ehp.9501.17384779
Wasserman, GA; Liu, X; Parvez, F; Ahsan, H; Factor-Litvak, P; van Geen, A; Slavkovich, V; Lolacono, NJ; Cheng, Z; Hussain, I; Momotaj, H; Graziano, JH. (2004). Water arsenic exposure and children’s intellectual function in Araihazar, Bangladesh. Environ Health Perspect 112: 1329–1333. 10.1289/ehp.6964.15345348
Wasserman, GA; Liu, X; Parvez, F; Chen, Y; Factor-Litvak, P; Loiacono, NJ; Levy, D; Shahriar, H; Uddin, MN; Islam, T; Lomax, A; Saxena, R; Gibson, EA; Kioumourtzoglou, MA; Balac, O; Sanchez, T; Kline, JK; Santiago, D; Ellis, T; van Geen, A; Graziano, JH. (2018). A cross-sectional study of water arsenic exposure and intellectual function in adolescence in Araihazar, Bangladesh. Environ Int 118: 304–313. 10.1016/j.envint.2018.05.037.29933234
Wasserman, GA; Liu, X; Parvez, F; Factor-Litvak, P; Ahsan, H; Levy, D; Kline, J; van Geen, A; Mey, J; Slavkovich, V; Siddique, AB; Islam, T; Graziano, JH. (2011). Arsenic and manganese exposure and children’s intellectual function. Neurotoxicology 32: 450–457. 10.1016/j.neuro.2011.03.009.21453724
Wasserman, GA; Liu, X; Parvez, F; Factor-Litvak, P; Kline, J; Siddique, AB; Shahriar, H; Uddin, MN; van Geen, A; Mey, JL; Balac, O; Graziano, JH. (2016). Child Intelligence and Reductions in Water Arsenic and Manganese: A Two-Year Follow-up Study in Bangladesh. Environ Health Perspect 124: 1114–1120. 10.1289/ehp.1509974.26713676
Wei, B; Yu, J; Wang, J; Yang, L; Li, H; Kong, C; Xia, Y; Wu, K. (2017a). The relationships between arsenic methylation and both skin lesions and hypertension caused by chronic exposure to arsenic in drinking water. Environ Toxicol Pharmacol 53: 89–94. 10.1016/j.etap.2017.05.009.28528304
Wei, BG; Ye, BX; Yu, JP; Yang, LS; Li, HR; Xia, YJ; Wu, KG. (2017b). Blood pressure associated with arsenic methylation and arsenic metabolism caused by chronic exposure to arsenic in tube well water. Biomed Environ Sci 30: 333–342. 10.3967/bes2017.044.
Welch, AH; Lico, MS; Hughes, JL. (1988). Arsenic in ground water of the Western United States. Groundwater 26: 333–347. 10.1111/j.1745-6584.1988.tb00397.x.
White, RF; Braun, JM; Kopylev, L; Segal, D; Sibrizzi, CA; Lindahl, AJ; Hartman, PA; Bucher, JR. (2022). NIEHS Report on Evaluating Features and Application of Neurodevelopmental Tests in Epidemiological Studies: NIEHS Report 01. Research Triangle Park (NC): National Institute of Environmental Health Sciences. 10.22427/NIEHS-01.
WHO (World Health Organization). (2000). Air quality guidelines for Europe (2nd ed.). Copenhagen, Denmark: World Health Organization, Regional Office for Europe. http://www.euro.who.int/en/health-topics/environment-and-health/air-quality/publications/pre2009/air-quality-guidelines-for-europe.
WHO (World Health Organization). (2004). Low birthweight: country, regional and global estimates. Geneva, Switzerland: World Health Organization and United Nations Children’s Fund (UNICEF). https://apps.who.int/iris/handle/10665/43184.
WHO (World Health Organization). (2011a). Evaluation of certain contaminants in food: Seventy-second report of the joint FAO/WHO expert committee on food additives (pp. 1–105, back cover). (WHO Technical Report Series, No. 959). http://whqlibdoc.who.int/trs/WHO_TRS_959_eng.pdf.
WHO (World Health Organization). (2011b). Safety evaluation of certain contaminants in food. (WHO Food Additives Series: 63. FAO JECFA Monographs 8). Geneva, Switzerland: prepared by the Seventy-second meeting of the Joint FAO/WHO Expert Committee on Food Additives (JECFA. http://whqlibdoc.who.int/publications/2011/9789241660631_eng.pdf.
Wilcox, AJ; Weinberg, CR; Basso, O. (2011). On the pitfalls of adjusting for gestational age at birth. Am J Epidemiol 174: 1062–1068. 10.1093/aje/kwr230.21946386
Wnek, SM; Medeiros, MK; Eblin, KE; Gandolfi, AJ. (2009). Persistence of DNA damage following exposure of human bladder cells to chronic monomethylarsonous acid. Toxicol Appl Pharmacol 241: 202–209. 10.1016/j.taap.2009.08.016.19699219
Wood, TC; Salavagionne, OE; Mukherjee, B; Wang, L; Klumpp, AF; Thomae, BA; Eckloff, BW; Schaid, DJ; Wieben, ED; Weinshilboum, RM. (2006). Human arsenic methyltransferase (AS3MT) pharmacogenetics: Gene resequencing and functional genomics studies. J Biol Chem 281: 7364–7373. 10.1074/jbc.M512227200.16407288
Wright, RO; Amarasiriwardena, C; Woolf, AD; Jim, R; Bellinger, DC. (2006). Neuropsychological correlates of hair arsenic, manganese, and cadmium levels in school-age children residing near a hazardous waste site. Neurotoxicology 27: 210–216. 10.1016/j.neuro.2005.10.001.16310252
Wu, C, -C; Huang, Y, -K; Chung, C, -J; Huang, C, -Y; Pu, Y, -S; Shiue, H, -S; Lai, L, -A; Lin, Y, -C; Su, C, -T; Hsueh, Y, -M. (2013). Polymorphism of inflammatory genes and arsenic methylation capacity are associated with urothelial carcinoma. Toxicol Appl Pharmacol 272: 30–36. 10.1016/j.taap.2013.05.019.23727622
Wu, C, -C; Su, C, -T; Lee, H, -L; Chung, C, -J; Huang, C, -Y; Pu, Y, -S; Lin, P; Hsueh, Y, -M. (2012a). Joint effect of arsenic methylation profile and NNK metabolites on urothelial carcinoma. J Urol 188: 1701–1705. 10.1016/j.juro.2012.07.025.22998908
Wu, F; Jasmine, F; Kibriya, MG; Liu, M; Cheng, X; Parvez, F; Paul-Brutus, R; Islam, T; Paul, RR; Sarwar, G; Ahmed, A; Jiang, J; Islam, T; Slavkovich, V; Rundek, T; Demmer, RT; Desvarieux, M; Ahsan, H; Chen, Y. (2014). Interaction between arsenic exposure from drinking water and genetic susceptibility in carotid intima-media thickness in Bangladesh. Toxicol Appl Pharmacol 276: 195–203. 10.1016/j.taap.2014.02.014.24593923
Wu, F; Jasmine, F; Kibriya, MG; Liu, M; Wójcik, O; Parvez, F; Rahaman, R; Roy, S; Paul-Brutus, R; Segers, S; Slavkovich, V; Islam, T; Levy, D; Mey, JL; van Geen, A; Graziano, JH; Ahsan, H; Chen, Y. (2012b). Association between arsenic exposure from drinking water and plasma levels of cardiovascular markers. Am J Epidemiol 175: 1252–1261. 10.1093/aje/kwr464.22534204
Wu, M, -M; Chiou, H, -Y; Hsueh, Y, -M; Hong, C, -T; Su, C, -L; Chang, S, -F; Huang, W, -L; Wang, H, -T; Wang, Y, -H; Hsieh, Y, -C; Chen, C, -J. (2006). Effect of plasma homocysteine level and urinary monomethylarsonic acid on the risk of arsenic-associated carotid atherosclerosis. Toxicol Appl Pharmacol 216: 168–175. 10.1016/j.taap.2006.05.005.16806340
Wu, MM; Chiou, HY; Chen, CL; Hsu, LI; Lien, LM; Wang, CH; Hsieh, YC; Wang, YH; Hsueh, YM; Lee, TC; Cheng, WF; Chen, CJ. (2011). Association of heme oxygenase-1 GT-repeat polymorphism with blood pressure phenotypes and its relevance to future cardiovascular mortality risk: an observation based on arsenic-exposed individuals. Atherosclerosis 219: 704–708. 10.1016/j.atherosclerosis.2011.08.047.21945498
Wu, MM; Chiou, HY; Chen, CL; Wang, YH; Hsieh, YC; Lien, LM; Lee, TC; Chen, CJ. (2010a). GT-repeat polymorphism in the heme oxygenase-1 gene promoter is associated with cardiovascular mortality risk in an arsenic-exposed population in northeastern Taiwan. Toxicol Appl Pharmacol 248: 226–233. 10.1016/j.taap.2010.08.005.20708634
Wu, MM; Chiou, HY; Ho, IC; Chen, CJ; Lee, TC. (2003). Gene expression of inflammatory molecules in circulating lymphocytes from arsenic-exposed human subjects. Environ Health Perspect 111: 1429–1438. 10.1289/ehp.6396.12928151
Wu, MM; Chiou, HY; Lee, TC; Chen, CL; Hsu, LI; Wang, YH; Huang, WL; Hsieh, YC; Yang, TY; Lee, CY; Yip, PK; Wang, CH; Hsueh, YM; Chen, CJ. (2010b). GT-repeat polymorphism in the heme oxygenase-1 gene promoter and the risk of carotid atherosclerosis related to arsenic exposure. J Biomed Sci 17: 70. 10.1186/1423-0127-17-70.20796278
Wu, Y; Ding, Y; Ramprasath, T, Zou, M. H. (2021). Oxidative stress, GTPCH1, and endothelial nitric oxide synthase uncoupling in hypertension. Antioxid Redox Signal 34: 750–764. 10.1089/ars.2020.8112.32363908
Xia, Y; Wade, TJ; Wu, K; Li, Y; Ning, Z; Le, XC; He, X; Chen, B; Feng, Y; Mumford, JL. (2009). Well water arsenic exposure, arsenic induced skin-lesions and self-reported morbidity in Inner Mongolia. Int J Environ Res Public Health 6: 1010–1025. 10.3390/ijerph6031010.19440430
Xiao, L; Zhou, Y; Ma, J; Sun, W; Cao, L; Wang, B; Zhu, C; Yang, S; Wang, D; Yuan, J; Chen, W. (2018). Oxidative DNA damage mediates the association between urinary metals and prevalence of type 2 diabetes mellitus in Chinese adults. Sci Total Environ 627: 1327–1333. 10.1016/j.scitotenv.2018.01.317.30857096
Xu, F; Chen, X, u; Zhang, H; Fan, Y; Song, Y, aP; Lv, J; Xie, Y; Huang, Y; Chen, D; Wang, H, ua; Xu, D, eX. (2022). Association between gestational arsenic exposure and intrauterine growth restriction: the role of folate content. Environ Sci Pollut Res Int 29: 89652–89661. 10.1007/s11356-022-21961-w.35857162
Xue, J; Zartarian, V; Wang, SW; Liu, SV; Georgopoulos, P. (2010). Probabilistic modeling of dietary arsenic exposure and dose and evaluation with 2003-2004 NHANES data. Environ Health Perspect 118: 345–350. 10.1289/ehp.0901205.20194069
Yang, A; Liu, S; Cheng, N; Pu, H; Dai, M; Ding, J; Li, J; Li, H; Hu, X; Ren, X; He, J; Zheng, T; Bai, Y. (2017). Multiple metals exposure, elevated blood glucose and dysglycemia among Chinese occupational workers. J Diabetes Complications 31: 101–107. 10.1016/j.jdiacomp.2016.07.022.27623387
Yang, T, seYen; Hsu, LI; Chen, H, uiChi; Chiou, HY, i; Hsueh, Y, uMei; Wu, MM; Chen, C, hiL; Wang, YH; Liao, Y, aT; Chen, CJ, en. (2013). Lifetime risk of urothelial carcinoma and lung cancer in the arseniasis-endemic area of Northeastern Taiwan. J Asian Earth Sci 77: 332–337. 10.1016/j.jseaes.2013.03.023.
Yildiz, A; Karaca, M; Biceroglu, S; Nalbantcilar, MT; Coskun, U; Arik, F; Aliyev, F; Yiginer, O; Turkoglu, C. (2008). Effect of chronic arsenic exposure from drinking waters on the QT interval and transmural dispersion of repolarization. J Int Med Res 36: 471–478. 10.1177/147323000803600311.18534128
Yu, D. (1999). A physiologically based pharmacokinetic model of inorganic arsenic. Regul Toxicol Pharmacol 29: 128–141. 10.1006/rtph.1999.1282.10341143
Yu, Y; Guo, Y; Zhang, J; Xie, J; Zhu, Y; Yan, J; Wang, B; Li, Z. (2017). A perspective of chronic low exposure of arsenic on non-working women: Risk of hypertension. Sci Total Environ 580: 69–73. 10.1016/j.scitotenv.2016.11.204.27951440
Yu, YX; Gao, MM; Wang, XP; Guo, YH; Pang, YM; Yan, HN; Hao, YX; Zhang, YL; Zhang, L; Ye, RW; Wang, B; Li, ZW. (2019). Recommended acceptable levels of maternal serum typical toxic metals from the perspective of spontaneous preterm birth in Shanxi Province, China. Sci Total Environ 686: 599–605. 10.1016/j.scitotenv.2019.05.413.31185407
Yuan, Y; Marshall, G; Ferreccio, C; Steinmaus, C; Selvin, S; Liaw, J; Bates, MN; Smith, AH. (2007). Acute myocardial infarction mortality in comparison with lung and bladder cancer mortality in arsenic-exposed region II of Chile from 1950 to 2000. Am J Epidemiol 166: 1381–1391. 10.1093/aje/kwm238.17875584
Yuan, Y; Xiao, Y; Feng, W; Liu, Y; Yu, Y; Zhou, L; Qiu, G; Wang, H; Liu, B; Liu, K; Yang, H; Li, X; Min, X; Zhang, C; Xu, C; Zhang, X; He, M; Hu, FB; Pan, A; Wu, T. (2017). Plasma metal concentrations and incident coronary heart disease in Chinese adults: The Dongfeng-Tongji cohort. Environ Health Perspect 125: 107007. 10.1289/EHP1521.29064788
Yuan, Y; Xiao, Y; Yu, Y; Liu, Y; Feng, W; Qiu, G; Wang, H; Liu, B; Wang, J; Zhou, L; Liu, K; Xu, X; Yang, H; Li, X; Qi, L; Zhang, X; He, M; Hu, FB; Pan, A; Wu, T. (2018). Associations of multiple plasma metals with incident type 2 diabetes in Chinese adults: The Dongfeng-Tongji Cohort. Environ Pollut 237: 917–925. 10.1016/j.envpol.2018.01.046.29429611
Zhang, C; Liu, C; Li, D; Yao, N; Yuan, X; Yu, A; Lu, C; Ma, X. (2010). Intracellular redox imbalance and extracellular amino acid metabolic abnormality contribute to arsenic-induced developmental retardation in mouse preimplantation embryos. J Cell Physiol 222: 444–455. 10.1002/Jcp.21966.19918794
Zhao, R; Hou, Y; Zhang, Q; Woods, CG; Xue, P; Fu, J; Yarborough, K; Guan, D; Andersen, ME; Pi, J. (2012). Cross-regulations among NRFs and KEAP1 and effects of their silencing on arsenic-induced antioxidant response and cytotoxicity in human keratinocytes. Environ Health Perspect 120: 583–589. 10.1289/ehp.1104580.22476201
Zheng, Y; Tao, S; Lian, F; Chau, BT; Chen, J; Sun, G; Fang, D; Lantz, RC; Zhang, DD. (2012). Sulforaphane prevents pulmonary damage in response to inhaled arsenic by activating the Nrf2-defense response. Toxicol Appl Pharmacol 265: 292–299. 10.1016/j.taap.2012.08.028.22975029
Zhou, T; Guo, J; Zhang, J; Xiao, H; Qi, X; Wu, C; Chang, X; Zhang, Y; Liu, Q; Zhou, Z. (2020). Sex-specific differences in cognitive abilities associated with childhood cadmium and manganese exposures in school-age children: A prospective cohort study. Biol Trace Elem Res 193: 89–99. 10.1007/s12011-019-01703-9.30977088
Zierold, KM; Knobeloch, L; Anderson, H. (2004). Prevalence of chronic diseases in adults exposed to arsenic-contaminated drinking water. Am J Public Health 94: 1936–1937. 10.2105/ajph.94.11.1936.15514231