# AUTHORS | CONTRIBUTORS | REVIEWERS

## Assessment Managers (Lead Authors)

J. Allen Davis, M.S.P.H.; Janice S. Lee, Ph.D. | EPA/ORD/CPHEA

## Authors

Ingrid L. Druwe, Ph.D.; Jeff Gift, Ph.D.; Ellen Kirrane, Ph.D.; Alexandra L. Lee, Ph.D.; Thomas Luben, Ph.D.; Martha Powers, Ph.D.; Rachel M. Shaffer, Ph.D. | EPA/ORD/CPHEA

## Executive Direction

Wayne Cascio, M.D., FACC (CPHEA Director); V. Kay Holt, M.S. (CPHEA Deputy Director); Samantha Jones, Ph.D. (CPHEA Associate Director); Kristina Thayer, Ph.D. (CPAD Director); Andrew Kraft, Ph.D. (CPAD Associate Director); Paul White, M.S. (CPAD Science Advisor) | EPA/ORD/CPHEA
Ravi Subramanian, Ph.D. (CPAD Science Advisor); Elizabeth Radke, Ph.D. (Branch Chief); Viktor Morozov, Ph.D. (Branch Chief); Shannon Hanna, Ph.D. (Branch Chief); Glenn Rice, Sc.D. (Branch Chief); Vicki Soto, B.S. (Branch Chief) | (retired)

## Contributors

Bevin E. Blake, Ph.D.; Ila Cote, Ph.D. (retired); Hisham El-Masri, Ph.D.; Karenna Roest, B.A.; Michele Taylor, Ph.D.; David Thomas, Ph.D. (retired) | EPA/ORD/CPHEA
Andrew Rooney, Ph.D.; Kiara Hodo, M.S.; Brittany Schulz, B.S. (former) | NIH/NIEHS/TTD; Oak Ridge Associated Universities (ORAU) Contractor

## Project Management and Production Team

Jack Rehmann (CPHEA Webmaster); Ryan Jones (HERO Director); Dahnish Shams (Project Management Team); Avanti Shirke (Project Management Team); Jessica Soto-Hernandez (Project Management Team); Samuel Thacker (HERO Team); Garland Waleko (Project Management Team) | EPA/ORD/CPHEA

## Contractor Support

Robyn Blain; Audrey DeLucia; Sorina Eftim; Susan Goldhaber; Ali Goldstone; Pamela Hartman; Cara Henning; Kevin Hobbie; Michelle Mendez; William Mendez, Jr.; Nicole Vetter | ICF
Bruce Allen | Allen Consulting LLC

## Reviewers

CPAD Executive Review Committee
Thomas Bateson | CPAD Senior Scientist
Todd Blessinger | CPAD Senior Scientist
John Bucher (retired) | NIEHS Senior Scientist
David Bussard (retired) | CPAD Senior Scientist
Vincent Cogliano (retired) | ORD Senior Scientist
Pamela Noyes (former) | CPAD Senior Scientist
Elizabeth Radke | CPAD Branch Chief
Paul White | CPAD Science Advisor
Epidemiology Workgroup
General Toxicity/Immunotoxicity/Cancer Workgroup
Pharmacokinetics Workgroup
Reproductive/Developmental/Neurotoxicity Workgroup
Statistics Workgroup
Systematic Review Workgroup
Toxicity Pathways/Genotoxicity Workgroup

## Agency Reviewers

This assessment was provided for review to scientists in EPA’s program and regional offices. Comments were submitted by:

- Office of the Administrator/Office of Children’s Health Protection
- Office of Air and Radiation/Office of Air Quality Planning and Standards
- Office of Chemical Safety and Pollution Prevention/Office of Pollution Prevention and Toxics
- Office of Land and Emergency Management
- Office of Water
- Region 2, New York City, NY
- Region 3, Philadelphia, PA
- Region 4, Atlanta, GA
- Region 8, Denver, CO
- Region 10, Seattle, WA

## Interagency Reviewers

This assessment was provided for review to other federal agencies and the Executive Office of the President. Comments were submitted by:

- Executive Office of the President
  - Office of Science and Technology Policy
  - Office of Management and Budget
- Department of Defense
- Department of Health and Human Services
  - National Institute of Environmental Health Sciences
  - National Institute of Occupational Safety and Health
  - National Library of Medicine
- U.S. Department of Agriculture