# 4 DOSE-RESPONSE ANALYSIS

## 4.1 INTRODUCTION

For this assessment, EPA evaluated and applied traditional (single-study), meta-analytical, and Bayesian dose-response methods to utilize a wider array of studies more fully in the derivation of toxicity values.

The iAs assessment provides multiple toxicity values for both cancer and noncancer endpoints in order to meet a broad range of stakeholder needs. For noncancer endpoints, the assessment includes the standard derivation of a reference dose (RfD) along with organ- or system-specific RfDs (osRfDs) via the application of uncertainty factors to points-of-departure (PODs). Certain decisions made by EPA Regional and Program Offices rely on the use of RfDs to meet their statutory requirements. Likewise, cancer slope factors (based on the 95^th^ percent upper bound on lifetime risk)^25^ are estimated for individual cancer endpoints and a combined cancer oral slope factor (OSF) is estimated based on bladder and lung cancers (Section 4.7). The iAs assessment also includes extensive results of the probabilistic Bayesian dose-response analyses for cancer and noncancer outcomes, where “risk-at-a-dose” values are presented across a range of low- to moderate iAs exposure scenarios. The PODs supporting the RfD are based on the lower confidence limit of the benchmark dose (BMDL) identified from the underlying Bayesian dose-response analyses for ischemic heart disease (IHD) and diabetes (Section 4.6).

Presentation of traditional, noncancer toxicity values (i.e., the RfD and osRfDs) as well as probabilistic toxicity values (i.e., risk-at-a-dose values) will allow users of the iAs assessment to estimate lifetime extra risk for individual endpoints at levels above the final RfD, noting that the definition of the RfD is “an estimate (with uncertainty spanning perhaps an order of magnitude) of a daily oral exposure to the human population (including sensitive subgroups) that is likely to be without an appreciable risk of deleterious effects during a lifetime.” Both the traditional and probabilistic toxicity values are useful within specific decision contexts. However, they involve different assumptions, methods, and uncertainties in their derivation. These results are carefully considered and discussed in this section.

The dose-response methods utilized by EPA were described and reviewed in the iAs protocol (see Appendix A) and are consistent with approaches described in the IRIS Handbook (U.S. EPA, 2022). EPA’s approach to the dose-response assessment and toxicity value derivations for iAs in this assessment is directly responsive to advice from NAS on the development of this IRIS assessment of iAs specifically (NASEM, 2019), as well as to more generalized NRC recommendations for expanding the use of Bayesian methods and taking a more consistent, unified approach for cancer and noncancer endpoints (NRC, 2009, 2013, 2014; NASEM, 2019). The dose-response methods used in this assessment rely on an estimate of “background” oral iAs intake of 0.365 μg/kg-day (comprising both drinking water and dietary exposure components) in the U.S. population. Population-specific exposure factors that influence the estimation of iAs intake (dose) were used to estimate a common dose measure (average lifetime μg/kg – day) to increase the number of studies that could be combined in the dose-response meta-analysis. The exposure factors came from reported exposure metrics (e.g., water concentrations) and empirical relationships between intake (dose) and reported urinary levels (in units of μg total urinary As/g creatinine), as established by a validated iAs PBPK model^26^. In addition, to take advantage of the large iAs epidemiological evidence base, dose-response meta-analysis methods were used to convert different reported exposure metrics to a common μg/kg-day dose metric (see Section 4.3.2). This common dose metric enabled studies using differing exposure metrics to be combined.

When possible, dose-response meta-analyses, such as those described in (Allen et al., 2020b; Allen et al., 2020a), are used to quantitatively combine results within a set of studies. This includes use of dose-response methods to convert reported incidence data to “effective counts” (see Section 4.3.3), which retains the study-specific control for confounding variables and use of the logistic-power model in order to include case-control and cohort studies in the same meta-analysis. The dose-response meta-analysis modeling approach used enables variability in the dose-response slope estimates to be quantified across study populations. To the extent possible, a variety of sensitivity analyses are performed in this assessment to quantitatively assess model uncertainty, exposure uncertainty, biological considerations, and individual and study population variability.

The endpoint-specific Bayesian dose-response meta-analyses of bladder and lung cancer, ischemic heart disease (IHD),^27^ and diabetes were used to derive model-based predictions of mean lifetime extra risk (with confidence intervals) above an exposure level of 0 μg/kg-day, across ranges of oral doses relevant to the U.S. population. In the assessment, these probabilistic risk values are presented in tables and the text as lifetime extra risk per 10,000 persons at various doses at and above the estimated iAs background dose (for cancer endpoints) and above the derived RfD (for non-cancer endpoints). Linear and/or polynomial equations are also provided to facilitate the estimation of extra risk at other doses for the modeled endpoints. The selected presentation of extra risk per 10,000 is done for illustration and context and does not represent a “threshold” recommendation, nor is this assessment recommending comparisons (e.g., between cancer and noncancer risk levels). In addition, while it is common practice for certain risk levels (i.e., 1 in a 1,000,000, 1 in 10,000, etc.) to be used by risk assessors when characterizing cancer risk values, this assessment is not suggesting risk levels for potential use in characterizing non-cancer and cancer risks.

The Bayesian dose-response meta-analysis modeling uses a prior distribution for the slope parameter that does not allow negative values. This decision is consistent with the causality conclusions drawn during hazard identification (see Section 4.3.4 for details), since a negative slope would identify decreasing risks for the identified health hazards with increasing iAs exposure. Further, this prior distribution is diffuse, and allows for the probability of both weak and strong associations between iAs exposure and disease, as informed by the modeled data. The hierarchical structure of the Bayesian dose-response meta-analysis model, which estimates separate slope parameters for each individual study data set, provides insight into dose-response heterogeneity and improves the quantification of overall uncertainty and variability.

This dose-response section summarizes (1) the results of an exposure-response screening analysis of epidemiological data sets to help prioritize health outcomes for dose-response (see Section 4.2); (2) Bayesian dose-response meta-analyses for four prioritized health outcomes: bladder cancer, lung cancer, IHD, and diabetes (see Section 4.3); and (3) dose-response analysis for two other prioritized health outcomes with data sets not suitable for Bayesian dose-response meta-analysis: fetal, newborn, and infant health outcomes (see Section 4.4) and neurodevelopmental cognitive effects (see Section 4.5). For cancer endpoints, risk estimates with confidence intervals and cancer slope factors (CSFs) are derived for bladder cancer (see Section 4.3.5) and lung cancer (see Section 4.3.6), and a combined cancer slope factor is derived in Section 4.7. Polynomial equations relating extra risk and dose above background are provided for these cancer types (Sections 4.3.5 and 4.3.6) as well as for IHD (Section 4.3.7) and for diabetes (4.3.8). For IHD; diabetes; fetal, newborn, and infant health outcomes; and neurodevelopmental cognitive effect, separate osRfDs are derived and a single, overall RfD is selected (Section 4.6).

## 4.2 EXPOSURE-RESPONSE SCREENING FOR ALL OUTCOMES

### 4.2.1 Overview of Screening Approach

To address the extensive inorganic arsenic evidence base (hundreds of epidemiological studies covering all causal or likely causal health outcomes), an exposure-response screening-level approach was developed (Hobbie et al., 2020) and applied to available dose-response data sets. The primary objectives of the exposure-response screening were to help prioritize health outcomes for dose-response analysis (i.e., identify health outcomes with modeling results close to U.S. background exposures), identify those that allow for multiple-study dose-response meta-analyses, select the most appropriate data sets for modeling, and provide screening-level relative risk estimates for a broad set of health outcomes potentially useful for cost-benefit considerations. The methods are described by Hobbie et al. (2020). The screening approach was applied to 12 of the health outcomes identified in the NRC “Hierarchy of Health End Points of Concern for Arsenic” (NRC, 2013) for which epidemiological evidence of an arsenic-association was determined robust or moderate^28^ (see the iAs Protocol [link provided in Appendix A, Section 2.3.1], Table 5-3). The screening analysis involved deriving and comparing study/data set-specific unitless ratios of the exposure associated with a defined relative risk increase over the background exposure (RRB) (Hobbie et al., 2020). This derivation was completed for all relevant data sets except those for the immune and developmental neurocognitive health outcomes. No appropriate dose-response data sets were identified for immune system health outcomes. The developmental neurocognitive health outcome was analyzed separately because all measured responses are continuous outcomes (e.g., IQ) that cannot be analyzed with this screening approach (Hobbie et al., 2020).

For the iAs exposure-response screening, the RRB estimates were derived by fitting standard parametric exposure-response models (e.g., logistic or Poisson regression) to the exposure metrics provided by study authors and deriving the exposure associated with a 20% increase in relative risk (RRE_20_). This RRE_20_ value was then divided an exposure estimate of either the population background or the mean background exposure for the study population to generate RRP-US and RRB-SP values, respectively (Hobbie et al., 2020). In addition to the RRB ratio value, another key factor in determining which outcomes to advance for further dose-response analysis was the number of data sets available for a given outcome. Full details of this screening analysis can be found in Appendix A and Hobbie et al. (2020).

Figure 4-1 shows individual and median health outcome-specific RRB-US results organized by highest to lowest number of supporting data sets and nature of the outcome (preclinical/subclinical, clinical nonfatal, or clinical fatal). As can be seen, DCS, bladder cancer, and lung cancer have by far the most extensive evidence base of the screening endpoints, and RRB values for 58, 53, and 28 studies were derived for these endpoints, respectively. Other endpoints that have previously been the focus of iAs assessments, namely skin cancer and skin lesions, had relatively fewer studies appropriate for RRB derivation (7 and 20, respectively). Further, DCS, bladder cancer, and lung cancer generally had lower median RRB-US values than other screened endpoints. These endpoints returned clinical nonfatal RRB-US values of 5.2 (DCS), 7.2 (bladder cancer), and 35.5 (lung cancer). Additionally, DCS and lung cancer had clinical fatal RRB-US values of 8.3 and 4.3. In comparison, skin lesions and skin cancer had generally higher clinical nonfatal RRB-US values of 42.2 and 18.8, respectively. The results of the RRB analysis, considering both the number of adequate supporting studies and the relatively high percentage of low RRB-US values^29^ derived from these studies (Hobbie et al., 2020), support EPA’s decision to perform higher-level dose-response analyses for bladder cancer (see Section 4.3.5), lung cancer (see Section 4.3.6), DCS (see Section 4.3.7). The RRB results (i.e., fewer studies available for analysis and/or higher RRB-US values) also support the decision not to perform higher-level dose-response analyses for skin lesions, renal cancer, liver cancer, immune effects, and skin cancer at this time. While initially not identified as a priority endpoint from the screening analysis, diabetes was also selected for higher-level dose-response analysis (see Section 4.3.8) given feedback from EPA’s program and regional offices. Although diabetes did have fewer available studies for analysis (n = 8), modeling this endpoint did result in relatively low median clinical nonfatal (3.99) and fatal (5.9) RRB-US values. Higher-level dose-response analyses were also performed for fetal, newborn, and infant health outcomes (see Section 4.4) and developmental neurocognitive effects (see Section 4.5), due primarily to their inclusion of potentially susceptible lifestages and their importance for EPA Program and Regional Office consideration in cost-benefit analyses.

Figure 4-1 Individual data set (solid symbols) and median (crosshatch symbols) relative risk increase over the U.S. background exposure (RRB-US) estimates for modeled health outcomes.^30^

## 4.3 BAYESIAN DOSE-RESPONSE META-ANALYSES

### 4.3.1 Identification of Studies and Data for Bladder Cancer, Lung Cancer, Ischemic Heart Disease, and Diabetes Dose-Response Meta-Analyses

The procedures used to select studies and evaluate data sets for inclusion in the Bayesian dose-response meta-analyses for bladder cancer, lung cancer, ischemic heart disease (IHD), and diabetes are described below. These same procedures were used for meta-analysis and/or individual dose-response analyses for fetal, newborn, and infant health outcomes (birth weight) and developmental neurocognitive effects (IQ score) described in Sections 4.4 and 4.5, respectively.

Multiple selection criteria and scientific considerations of particular topics important for EPA’s dose-response meta-analysis approach were considered to identify the most appropriate study data sets for use in the dose-response meta-analyses and individual study analyses:

1. Selection criteria:
  a. Study design; Case-control or cohort for bladder cancer, lung cancer, IHD, and diabetes. Cross-sectional studies were excluded for all but the fetal, newborn, and infant health and developmental neurocognitive meta-analyses. Ecological studies were excluded from all analyses.
  b. Exposure metrics: Use of exposure metric that is or can be converted to an oral ingestion rate such as drinking water concentrations or creatinine-adjusted urinary concentrations. Studies using other biomarkers (e.g., blood and hair concentrations) were excluded from the dose-response analyses due to uncertainties in converting those metrics to oral doses. For studies conducted in adult populations, the empirical relationship derived using the El-Masri-Kenyon PBPK model (El-Masri and Kenyon, 2008; El-Masri et al., 2018a, b) allows for the conversion of urine biomarker data (measured in μg tAs/g creatinine) to oral doses, Urine biomarker data based on use of specific gravity as the method for urinary correction were excluded for adult data because that fell outside the application domain of the El-Masri-Kenyon PBPK model. The empirical relationship reported in Moon et al. (2013) allows the conversion of toenail iAs concentrations into drinking water concentrations. For birth weight and developmental neurocognitive effects, maternal urinary total As concentrations were converted to drinking water exposures using the relationship established in Gilbert-Diamond et al., 2016. Specific gravity-corrected urinary biomarker data were considered for birth weight and developmental neurocognitive outcomes given the El-Masri-Kenyon PBPK model was not being used for dose conversions. For birth weight and developmental neurocognitive effects, the toenail studies were excluded because of the uncertainty in applying Moon et al. (2013) to maternal samples.
  c. Smoking: Smoking is associated with both arsenic exposure and the outcomes evaluated in this assessment (Sasco et al., 2004; Salihu and Wilson, 2007; Ockene and NH, 1997; Corrêa et al., 2021; Chen et al., 2013a; ADA, 2004). As such, whether smoking was adequately addressed in the study design and/or analysis was a key criteria for dose-response study selection. If a study did not mention smoking or how the authors addressed confounding due to tobacco smoke exposure and smoking rates in the population were anticipated to be non-negligible, the study was excluded from consideration for dose-response.
  d. Appropriate risk metrics reported: RR, OR, or HR were necessary inputs for the Bayesian dose-response meta-analysis; beta coefficients were the necessary inputs for the birth weight and developmental neurocognitive meta-analyses.
  e. Quantitative exposure reporting: numeric exposure groups characterization was necessary for dichotomous endpoints modeled with the Bayesian dose-response meta-analysis approach whereas study-reported beta coefficients were used for the continuous birth weight and developmental neurocognitive endpoints.
  f. Number of cases, controls, person-years: the numbers of cases, controls, and person-years was a necessary input for the Bayesian dose-response meta-analyses.
  g. Prioritization of endpoints: some health endpoints within a larger domain were prioritized for dose-response modeling. For example, within the larger domain of diseases of the circulatory system, ischemic heart disease was prioritized. Likewise, for fetal, newborn, and infant health outcomes, decreased birth weight was prioritized (see endpoint-specific study selection sections for more details). Three studies are considered the minimum amount that is sufficient to base a dose-response meta-analysis; outcomes with less than three studies were therefore excluded from further analysis.
2. Other scientific considerations important for dose-response modeling:
  a. To enhance the relevance and precision of the meta-analyses, EPA prioritized including studies for which exposures were low to moderate and well-characterized, recognizing a large proportion of available studies evaluated populations with exposures much higher than commonly experienced in the United States. Thus, this analysis does not include studies of populations within southwest Taiwan, where exposures are not well-characterized, and diseases associated with historically high arsenic exposures have been “endemic” for centuries. Some studies that could be considered moderate to high exposure such as Bangladeshi or Chilean studies were included because they included potentially susceptible subpopulations that received well-characterized^31^ exposures for a relatively short period of time: 1958–1970). The inclusion of potentially susceptible subpopulations in the dose-response meta-analysis data sets helps address concerns related to the potential presence of genetic polymorphisms, inadequate nutrition, or other differences that can influence dose-response sensitivity. Selecting diverse studies also facilitates the investigation of heterogeneity in arsenic-related dose-response.
  b. Exclusion of duplicate study populations: Usage of multiple studies from the same population was a consideration in the revised study selection workflow such that duplicate study populations were not used in the same meta-analysis. When multiple studies covered the same study population, only a single representative study was used in the dose-response meta-analysis. For cohort studies conducted using the same cohort population, studies that included a longer follow-up period were generally preferred. However, some cases studies with shorter follow up were selected for inclusion if other characteristics (e.g., more dose groups) favored their use over other studies. When case-control studies drawn from the same study population, only one study was included and studies with longer recruitment periods and greater numbers of cases were preferred. Note that when two case-control studies are conducted in the same geographic population, both are included in the dose-response meta-analysis if they fulfill the requirement of nonoverlapping recruitment periods and all other study-selection criteria.
  c. Confirmation of no significant analysis or exposure issues: occasionally, additional study details were considered regarding the suitability of individual studies for inclusion in the dose-response meta-analyses. For example, studies where the exposure range was narrow, and the largest dose group differed by less than 20% of the reference dose were excluded from the dose-response analysis (see study selection for lung cancer). Another example is exclusion of birth weight studies that reported beta coefficients for the z-score for birth weight and not the beta coefficient for the unstandardized birth weight. Datasets that considered the contribution of arsenobetaine (or accounted for seafood consumption) were preferred when available. These confirmatory analysis or exposure issues are discussed in detail in the endpoint-specific sections below. A number of “leave-one-out” sensitivity analyses were also conducted to explore the impact of issues on dose-response results.
  d. Model covariates: Because diabetes and/or hypertension could be on the causal pathway between arsenic exposure and IHD outcomes (Moon et al., 2013), models that did not adjust for those outcomes were preferred when selecting estimates for dose-response.

At least two reviewers independently evaluated studies according to the above selection criteria and scientific considerations. Reviewers then discussed judgments and resolved any differences.

#### Identification of Studies for Bladder Cancer Dose-Response Analysis

Sixty-one medium or [underlined: high] confidence studies with exposure- or dose-response data were considered for dose-response, from which 11 studies (11 data sets) were selected for the final bladder cancer dose-response meta-analysis on the basis of criteria outlined above (see Figure 4-2).

Figure 4-2 Study selection flow for identification of studies for bladder cancer Bayesian dose-response meta-analysis (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Dose-Response-Inclusion/))

##### Data sets selected for urinary/bladder cancer dose-response meta-analysis

Ultimately, 11 studies were included in the dose-response meta-analysis: one cohort study (Chen et al., 2010b), and 10 case-control studies (Wu et al., 2013; Steinmaus et al., 2003; Steinmaus et al., 2013; Michaud et al., 2004; Meliker et al., 2010; Karagas et al., 2004; Chang et al., 2016; Bates et al., 1995; Bates et al., 2004; Baris et al., 2016). Five data sets were from U.S. populations, three from Northeast or Northwest Taiwan, and one each from Argentina, northern Chile, and Finland. See interactive HAWC figure (https://hawc.epa.gov/summary/visual/assessment/100500243/Dose-Response-Inclusion/) for full list of which studies were excluded under each selection criterion/consideration. The order of appearance of the criteria/consideration in the HAWC figure above reflects the sequence of application (i.e., confirmation of exposure metric was the first screening criteria). Most studies were excluded because they were not cohort or case-control studies, presented duplicative study population data, did not use drinking water, urine, or toenail as the exposure metric, or did not present a RR, OR, or HR as the risk metric. Four studies conducted in SW Taiwan were excluded (Huang et al., 2008a; Hsu et al., 2008; Chiou et al., 1995; Chen et al., 2003). Multiple studies were excluded with respect to the duplicative study population consideration. Steinmaus et al. (2014a), Steinmaus et al. (2015) and Ferreccio et al. (2013) were excluded because these studies investigated the effect of iAs on bladder cancer in population subsets of the main study population (Steinmaus et al., 2013; Chiou et al., 2001a) was an earlier study in the same cohort that was superseded by a later study (Chen et al., 2010b). Yang et al. (2013) was a later study in the same cohort analyses in Chen et al. (2010b) but was not selected for dose-response because it had fewer dose groups than Chen et al. (2010b). Many studies (Wu et al., 2012a; Pu et al., 2007; Lin et al., 2018; Huang et al., 2008b; Huang et al., 2018; Chung et al., 2011a; Chung et al., 2013a) were case-control studies whose recruitment overlapped with Wu et al. (2013). Additionally, one study was excluded because it was a mortality study (studies of bladder cancer incidence was preferred) (D’Ippoliti et al., 2015).

The exposure or intake metrics authors used include lifetime cumulative arsenic intake (from water), daily average intake from water, cumulative exposure (μg/L*years in water), urinary arsenic concentration (μg/g creatinine), and toenail concentration. To support the dose-response meta-analysis, all exposure, intake, and excretion metrics were converted to estimates of lifetime daily arsenic intake. Ranges of estimates for lifetime daily arsenic intake (based on maximum likelihood estimation) and U.S.-equivalent drinking water exposure for each study are also reported in Appendix C.1.2, Table C-25.

Urine biomarker metrics of iAs dose were evaluated against bladder cancer incidence in two hospital-based data sets, consisting of subjects recruited from the National Taiwan University Hospital and the Taipei Municipal Wan Fang Hospital in Northeast Taiwan (Wu et al., 2013) and the China Medical University Hospital located in Midwest Taiwan in the city of Taichung (Chang et al., 2016). EPA estimated daily arsenic intake using the empirical relationship established by the El-Masri-Kenyon PBPK model of the relationships between inorganic arsenic intake and total (inorganic and organic) arsenic urinary excretion (El-Masri and Kenyon, 2008; El-Masri et al., 2018b; El-Masri et al., 2018a).^32^ An important consideration is this Northeast Taiwan study population has been the subject of multiple additional epidemiological investigations (Pu et al., 2007; Huang et al., 2008a; Chung et al., 2011b;Wu et al., 2012a; Chung et al., 2013b; Huang et al., 2018; Lin et al., 2018), all finding similar relationships between bladder cancer and low-level urinary arsenic excretion. This finding corroborates that at least recent exposures from water are consistent with the observed arsenic excretion values.

As noted in Section 1.6.2, ingestion of seafood can result in arsenobetaine contributing to the measured total urinary arsenic concentrations and bias results to the null given that arsenobetaine is a nontoxic species. Therefore, studies using urinary biomarkers to characterize exposure that account for this are preferred as exclusion of nontoxic organic arsenicals may reduce misclassification. Of the two bladder cancer studies using urinary total As to characterize exposure, one (Wu et al., 2013) excluded arsenobetaine in the urinary As concentrations. The other (Chang et al., 2016) stated that it included all organic and inorganic arsenic species in their exposure characterization. The degree to which this study influenced the final modeling results for the dose-response meta-analysis was investigated via the leave-one-out sensitivity analysis discussed in Appendix C.1.2 (Bladder Cancer, Bladder cancer sensitivity analyses). In brief, the sensitivity analysis demonstrated that exclusion of this study did not greatly impact modeling results and only increased the pooled slope parameter by approximately 9% (see Table C-28). EPA found overlap between the studies included in the current dose-response meta-analysis and those identified in six earlier meta-analyses (see Appendix C.1.2, Table C-23). Of the 11 studies chosen by EPA, a core group of five studies were included for all analyses (Meliker et al., 2010; Bates et al., 2004; Baris et al., 2016). Additionally, two studies (Steinmaus et al., 2013; Chen et al., 2010b) were included in five of the six meta-analyses. Many studies selected for the earlier meta-analysis that were not used in the EPA dose-response meta-analysis were studies that were superseded by later analyses of the same study populations or were studies that were judged to be too uncertain regarding exposure measurements (see Appendix C.1.2: Bladder Cancer for more details). In part because of the availability of the El-Masri-Kenyon PBPK model, two recent urine biomarker studies (Wu et al., 2013; Chang et al., 2016) were included in EPA’s meta-analysis that were not included in any of the previous meta-analysis. Other studies were not published at the time most of these authors began their literature reviews (Saint-Jacques et al., 2014; Lynch et al., 2017b; Shao et al., 2021).

#### Identification of Studies for Lung Cancer Dose-Response Analysis

Sixty-five medium or high confidence studies were considered for dose-response, from which six studies were selected to analyze lung cancer dose-response meta-analysis (see Figure 4-3).

Figure 4-3 Study selection flow for identification of studies for lung cancer Bayesian dose-response meta-analysis (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Dose-Response-Inclusion/))

##### Data sets selected for lung cancer dose-response meta-analysis

Ultimately, six studies were included in the dose-response meta-analysis: three cohort studies (García-Esquinas et al., 2013; Chen et al., 2010a; Argos et al., 2014) and three case-control studies (Steinmaus et al., 2013; Ferreccio et al., 2000; Dauphiné et al., 2013). See interactive HAWC figure (https://hawc.epa.gov/summary/visual/assessment/100500243/Dose-Response-Inclusion/) for full list of which studies were excluded under each selection criterion/consideration. The order of appearance of the criteria/consideration in the HAWC figure above reflects the sequence of application (i.e., confirmation of exposure metric was the first screening criteria). Most studies were excluded because they did not use drinking water, urine, or toenail concentrations as the exposure metric, were not cohort or case-control studies, or presented duplicative study population data. Two studies conducted in SW Taiwan were excluded (Chiou et al., 1995; Chen et al., 2004). With respect to duplicative study population data, Steinmaus et al. (2014b), Steinmaus et al. (2014a), Steinmaus et al. (2015) and Ferreccio et al. (2013) investigated the effect of iAs on lung cancer in population subsets of the full study population . Yang et al. (2013) was a later study in the same cohort analyses in Chen et al. (2010a) but was not selected for dose-response because it had fewer dose groups than Chen et al. (2010a). Additionally, two other studies were excluded based on concerns over exposure characterization. Mostafa et al. (2008) characterized exposure based on the mean water concentration for the entire administrative district study participants lived in. Heck et al. (2009) was excluded because, across the entire dose range of the study, exposures only increased by less than 20%.

Appendix C.1.2, Table C-33 lists the six studies selected for inclusion in the Bayesian dose-response meta-analysis for lung cancer. One study was from Northeast Taiwan, one from Bangladesh, and two each from U.S. populations and northern Chile. The exposure or intake metrics authors used include drinking water concentrations, daily average intake from water, cumulative exposure (μg/L*years), urinary arsenic excretion (μg/g creatinine), and toenail concentration (μg/g). Section 4.3.2 describes the approach to addressing exposure measurement uncertainties and estimating arsenic daily intake.

As noted above, EPA estimated daily arsenic intake for two data sets [Argos et al. (2014) and García-Esquinas et al. (2013)], using the empirical relationship between urinary and drinking water concentrations established by the El-Masri and Kenyon PBPK model of the relationships between inorganic arsenic intake and total (inorganic and organic) arsenic urinary excretion (El-Masri and Kenyon, 2008; El-Masri et al., 2018b; El-Masri et al., 2018a).^33^ The As intakes estimated in the Argos et al. (2014) study (1.85−18.91 μg/kg-day) are generally in line with those estimated for other selected non-U.S. data sets. Although the estimated daily intakes for García-Esquinas et al. (2013) (0.14−0.58 μg/kg-day) are lower, they are comparable to the other U.S. data set [i.e., Dauphiné et al. (2013): 0.11−2.6], especially at the low end of the exposure range. This makes the García-Esquinas et al. (2013) and Dauphiné et al. (2013) data sets the most sensitive or “critical” studies in the dose-response meta-analysis database. Note that exposure misclassification due to arsenobetaine from seafood ingestion is not a concern for these two studies because the study was either conducted in a population with low seafood consumption or arsenobentaine was measured and observed to contribute a very small (~3%) of the total urinary arsenic concentration.

EPA found considerable overlap between the studies included in the EPA dose-response meta-analysis and those identified in earlier meta-analysis (see Appendix C.1.2, Table C-34). Of the six studies chosen by EPA, only one study (Chen et al., 2010a) was used in all earlier meta-analyses. Two other studies used in the EPA meta-analysis (Dauphiné et al., 2013; Steinmaus et al., 2013) were included in all but one earlier meta-analyses. a core group of five studies were chosen for all; or for all but one (Mostafa et al., 2008; D’Ippoliti et al., 2015) of the meta-analyses published after the eight studies identified by EPA. The four studies selected for the earlier meta-analyses not used in the current dose-response meta-analysis were determined unsuitable because they were conducted in the southwest Taiwan “endemic” region (Chiou et al., 1995; Chen et al., 2004), were re-analyses that used much wider exposure ranges in the low-dose region compared with the original study (Ferreccio et al., 2000), had an unsuitably narrow exposure range (i.e., less than 20% increase in exposure across entire exposure range) (Heck et al., 2009), or were superseded by a later study using the same cohort (Chen et al., 2004).

#### Identification of Outcomes and Studies for IHD Dose-Response Analysis

Diseases of the circulatory system (DCS)^34^ is a broad term used in this assessment to encompass ischemic heart disease (IHD),^35^ stroke, high blood pressure, and peripheral artery disease. As discussed in Section 3.2.1, these DCS outcomes have all been linked to iAs exposure. Studies of clinically diagnosed IHD alone, however, have reported dose-response relationships with iAs that generally are stronger than the dose-response relationships for other DCS outcomes, including hypertension and stroke (Moon et al., 2017b). Moreover, NRC (2013) identified IHD as the highest priority DCS outcome for EPA’s iAs assessment. For these reasons, the Bayesian dose-response meta-analyses for dose-response described in this section focuses on studies that involve clinical diagnoses of two DCS outcome categories: IHD incidence and IHD fatality.

One hundred and fifty-four medium or high confidence studies were considered for dose-response, from which seven studies (eight data sets) were selected for the final IHD dose-response meta-analysis (see Figure 4-4).

Figure 4-4 Study selection flow for identification of studies for DCS Bayesian dose-response meta-analysis (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Dose-Response-Inclusion/))

##### Data sets selected for IHD dose-response meta-analyses

Ultimately, seven studies were initially identified for inclusion in the dose-response meta-analysis: six cohort studies (Wu et al., 2010b; Nigra et al., 2021; Moon et al., 2013; James et al., 2015; Chen et al., 2011b; Chen et al., 2013c), and one case-control study (Wade et al., 2015). Of these studies, three studies presented information on IHD mortality. However, one IHD mortality study adjusted for urinary dilution via specific gravity (Nigra et al., 2021) and the El-Masri–Kenyon PBPK model (El-Masri and Kenyon, 2008; El-Masri et al., 2018b; El-Masri et al., 2018a) was not able to estimate drinking water concentrations for this study (as the empirical relationship established by the PBPK model is between drinking water concentrations and creatinine-adjusted urinary As concentrations). This left only two remaining IHD mortality-only studies (Moon et al., 2013; Chen et al., 2011b), considered too few to form the basis of a dose-response meta-analysis. Thus, only the five remaining IHD studies that included incident-only cases or incident plus fatal cases were ultimately modeled.

See interactive HAWC figure (https://hawc.epa.gov/summary/visual/assessment/100500243/Dose-Response-Inclusion/) for full list of which studies were excluded under each selection criterion/consideration. The order of appearance of the criteria/consideration in the HAWC figure above reflects the sequence of application (i.e., confirmation of exposure metric was the first screening criteria). Most studies were excluded because they were not cohort or case-control studies, did not use drinking water, urine, or toenail as the exposure metric, did not present a RR, OR, or HR as the risk metric, or did not present information on the prioritized outcomes of CVD or IHD. Six studies conducted in SW Taiwan were excluded (Wang et al., 2002; Tseng et al., 2003; Hsueh et al., 1998; Hsieh et al., 2008b; Chiou et al., 2001b; Chen et al., 1996). Two studies (Wu et al., 2006; Wang et al., 2007) were excluded as duplicate populations of the Wu et al. (2010b) study. Appendix C.1.2, Table C-50 summarizes the five studies, four cohort studies and one case-control study selected for inclusion in the Bayesian dose-response meta-analyses of IHD after dose-response study quality considerations. All the cohort studies were deemed to have involved adequate follow-up durations for IHD health outcomes to occur.^36^ The third column of Table C-50 indicates the exposure or intake metrics authors reported; these include daily average intake from water (μg/L) and cumulative exposure (μg/L*years in water) and urinary arsenic excretion (μg/g creatinine). To support the dose-response meta-analysis, all exposure, intake, and excretion metrics were converted to estimates of lifetime daily arsenic intake.

For the Moon et al. (2013) and James et al. (2015) studies, all daily dose and equivalent U.S. drinking water level estimates for the exposure groups are in the range of U.S. doses (<1 μg/kg-day) and U.S. drinking water levels (<100 μg/L). Thus, the results from the Moon et al. (2013) and James et al. (2015) arsenic studies are considered most relevant for assessing the relationship between the relatively low levels of arsenic daily intake most U.S. populations experience and IHD outcomes. Note that exposure misclassification due to arsenobetaine from seafood ingestion was a concern for one urinary biomarker study for IHD (Chen et al., 2013c) because the study did not report that it was conducted in a population in which arsenobentaine was measured or report that arsenobetaine was observed to contribute a very small percentage of the total urinary arsenic concentration. The degree to which this study influenced the final modeling results for the dose-response meta-analysis was investigated via the leave-one-out sensitivity analysis discussed in Appendix C.1.2 (IHD sensitivity analyses). In brief, the sensitivity analysis demonstrated that exclusion of this study had a moderate impact on modeling results, increasing the pooled slope parameter by approximately 30% (see Table C-57).

There was some overlap between the studies included in the EPA dose-response meta-analysis and those identified in earlier meta-analysis (see Appendix C.1.2, Table C-51). A recent meta-analysis, Moon et al. (2017b) that succeeds a previous meta-analysis by the same group (Moon et al., 2012) was identified. The IHD studies selected by Moon et al. (2017b) but excluded from the EPA dose-response meta-analysis are Rahman et al. (2014), Sohel et al. (2009), Wang et al. (2005), Wade et al. (2009), Farzan et al. (2015a), D’Ippoliti et al. (2015), and Chen et al. (1996). Farzan et al. (2015a) was not included due lack of exposure group quantitative results (i.e., analyses treated arsenic as a continuous variable), Chen et al. (1996) is a study of townships in southwest Taiwan with endemic arseniasis that has experienced very high iAs exposures not relevant to U.S. populations, Wade et al. (2009) reported incident rate ratios instead of relative risks, and D’Ippoliti et al. (2015) did not control for smoking on the individual level, Sohel et al. (2009) did not control for smoking, and Rahman et al. (2014) and Wang et al. (2005) did not investigate IHD endpoints.

#### Identification of Outcomes and Studies for Diabetes Dose-Response Analysis

Ninety-seven medium or high confidence studies were considered for dose-response, from which four studies were selected for the final diabetes dose-response meta-analysis (see Figure 4-5).

Figure 4-5 Study selection flow for identification of studies for diabetes Bayesian dose-response meta-analysis (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Dose-Response-Inclusion/))

##### Data sets selected for diabetes dose-response meta-analysis

Ultimately, four studies were included in the dose-response meta-analysis: three cohort studies (Pan et al., 2013b; James et al., 2013; Grau-Perez et al., 2017), and one case-control study (Coronado-González et al., 2007). See interactive HAWC figure (https://hawc.epa.gov/summary/visual/assessment/100500243/Dose-Response-Inclusion/) for full list of which studies were excluded under each selection criterion/consideration. The order of appearance of the criteria/consideration in the HAWC figure above reflects the sequence of application (i.e., confirmation of exposure metric was the first screening criteria). The most common reasons were not using drinking water or urine as the exposure metric, not being a cohort or case-control study, or not being a study of type 2 diabetes incidence, i.e., a study of diabetes mortality was not included (D’Ippoliti et al., 2015). Other exposure considerations that led to exclusion were studies being conducted in southwest Taiwan (Tseng et al., 2000; Hsu et al., 2013), reporting of exposure on the log scale (Rangel-Moreno et al., 2022), or very low doses determined by geographic analysis (Bräuner et al., 2014).

Appendix C.1.2, Table C-42 lists the four data sets selected for inclusion in the Bayesian dose-response meta-analysis for diabetes. One data set was from Bangladesh, one was from Mexico, and two were from the United States. The exposure or intake metrics the authors used include lifetime cumulative arsenic intake (from water), drinking water concentration, and urinary arsenic excretion (μg/g creatinine). To support the dose-response meta-analysis, all exposure, intake, and excretion metrics were converted to estimates of lifetime daily arsenic intake.

As noted above, EPA estimated daily arsenic intake for two data sets (Coronado-González et al., 2007; Grau-Perez et al., 2017), on the basis of the empirical relationship between urinary and drinking water concentrations established by the El-Masri–Kenyon PBPK model of the relationships between inorganic arsenic intake and total (inorganic and organic) arsenic urinary excretion (El-Masri and Kenyon, 2008; El-Masri et al., 2018b; El-Masri et al., 2018a).^37^ . The estimated daily iAs intakes for Coronado-González et al. (2007) (1.3–4.56 μg/kg-day) is generally in line with the estimated daily intakes for other selected non-U.S. data sets. The estimated daily intake for Grau-Perez et al. (2017) (0.07–0.28 μg/kg-day), however, is lower than those data sets and is more comparable to the other U.S. data sets used for other endpoints [e.g., the lung cancer Dauphiné et al. (2013) study: 0.11−2.6 μg/kg-day]. The James et al. (2013) cumulative exposure study is also associated with relatively low iAs daily intake values: 0.135–0.608 μg/kg-day. This makes the Grau-Perez et al. (2017) and James et al. (2013) studies the studies that represent the lowest exposure ranges in the dose-response meta-analysis database for type 2 diabetes. Note that exposure misclassification due to arsenobetaine from seafood ingestion is not a concern for the two urinary biomarker studies because the study was either conducted in a population with low seafood consumption (Coronado-González et al., 2007) or arsenobentaine was not included in the estimation of total urinary arsenic concentrations and sensitivity analyses investigating including arsenobetaine as a confounder in models showed no difference to the main analyses (Grau-Perez et al., 2017).

Wang et al. (2014) performed the only meta-analyses comparable to the EPA dose-response meta-analysis approach in that it involved dose-response meta-analysis modeling of multiple studies of the relation between type 2 diabetes and inorganic arsenic exposure. It differed from the EPA analysis in that it included cross-sectional studies and studies conducted of the iAs endemic region of SW Taiwan region. Of the four diabetes studies used in the EPA analysis, two were included in the Wang et al. (2014) analysis, James et al. (2013) and Coronado-González et al. (2007), but the two later publications, Pan et al. (2013b) and Grau-Perez et al. (2017), were not.

### 4.3.2 Estimating a Common Dose Metric and Dose Uncertainty for Bladder Cancer, Lung Cancer, Diseases of the Circulatory System, and Diabetes Dose-Response Meta-Analyses

The conversion of study-specific exposure metrics to a common dose metric is an essential aspect of the dose-response meta-analysis approach used by EPA as it allows multiple studies to be combined, which increases the precision of the dose-response modeling results. Allen et al. (2020a) describes methods for performing these dose conversions, and they are also summarized in the updated iAs Protocol, Section 5.2 (see Appendix A) and Appendix C.1.1. Additional details on the methods for treating dose uncertainty are provided in Appendix C.1.1 (Treatment of Dose Uncertainty). Of particular note is that by calculating a common dose metric, the present analysis can include studies that used urinary or toenail biomonitoring as the exposure assessment method and studies that assessed exposure on the basis of drinking water intake. Applications of the empirical relationship between urinary tAs concentrations and drinking water concentrations, as established by the El-Masri–Kenyon PBPK model (El-Masri and Kenyon, 2008; El-Masri et al., 2018b; El-Masri et al., 2018a) or the relationship between toenail As concentration and drinking water exposure (Moon et al., 2013) are considered to provide reliable estimates of total arsenic dose and average lifetime daily intake (μg/kg-day) (Allen et al., 2020a; Allen et al., 2020b). Urinary and toenail arsenic measurements integrate all sources of oral exposure at the individual level, accounting for arsenic from both water and diet, an important recommendation of NRC, (2013) and are considered a high-quality biomarker of internal dose (NRC, 1999; Hughes, 2006; Marchiset-Ferlay et al., 2012).

Dose uncertainty was addressed using the two-step approach described by Allen et al. (2020a) and in Appendix C.1.1 (Treatment of Dose Uncertainty). This two-step approach involved deriving estimates for the low, maximum likelihood estimate (MLE), and high exposure-group means.^38^ These estimates then were used in a Monte Carlo analysis, along with distributional representations of individual variability of exposure-to-intake conversion factors, to estimate low (5th percentile), MLE, and high (95th percentile) average μg/kg-day intake doses (Allen et al., 2020a). Appendix C.1.2 provides the three selected sets of dose values (in average μg iAs/kg-day) used in the analyses of bladder cancer, lung cancer, diabetes, and IHD. Appendix C.1.1 (Treatment of Dose Uncertainty) provides details of the study-specific conversions.

### 4.3.3 Estimating Effective Counts for Bladder Cancer, Lung Cancer, Diseases of the Circulatory System, and Diabetes Dose-Response Meta-Analyses

To further expand the number of studies that could be included in the iAs dose-response meta-analysis approach, data adjustments were also made to the response measures (counts of affected and nonaffected individuals) reported in the studies considered for use. These data adjustments result in “effective counts”—noninteger incidence data that consider the controls for confounding that the individual study authors performed, which allows for case-control and cohort studies to be included in the same dose-response meta-analysis. Essentially, effective counts produce the adjusted OR or RR the study authors report after controlling for confounders. The methods and rationale for deriving effective counts for such study types, described by Allen et al. (2020a) and in Appendix C.1.1 (Adjusting for Covariates), were applied to the bladder cancer, lung cancer, IHD, and diabetes data sets. The resulting effective counts for these four data sets are presented in endpoint-specific subsections of Appendix C.1.2.

### 4.3.4 Methods Used to Conduct Dose-Response Meta-Analysis and Estimate U.S. Lifetime Extra Risk for Bladder Cancer, Lung Cancer, Diseases of the Circulatory System, and Diabetes

The dose-response meta-analyses for bladder cancer, lung cancer, IHD and diabetes were conducted using Bayesian-derived methods. A logistic-power model was used because it allows for a unified, consistent analysis of both case-control and cohort studies together in a single dose-response meta-analysis (Allen et al., 2020a; Allen et al., 2020b). The basic equation relating dose to response is

l o g i t { P r ( D = 1 ∣ X ) } = α^∗^ + β^T^ s (X^q^) (4-1)

where pr(D = 1|X) is the probability of having the disease (D = 1 as opposed to D = 0), which is conditional on the values of the explanatory variables, X, having p components X_1_, …, X_p_. Here, s(x) is a specified, fixed function and s(x) = (s_1_(x_1_), …, s_p_(x_p_)). The motivations and methods for implementing such an analysis are described by Allen et al. (2020b) and in Appendix C.1.1 (Bayesian Dose-Response Meta-Analysis Methods). X is scalar (having the value of iAs dose in μg/kg-day) and s(x) = x, so β (i.e., the slope) is also a scalar. The q parameter is the exponent on the explanatory dose variable x.

The hierarchical structure for the dose-response meta-analysis assumes the α* parameter was separate and independent for each data set (Allen et al., 2020b). Study-specific β values that were normally distributed around a mean (β_mean) with some standard deviation (β_sigma) were assumed. Both β_mean and β_sigma are estimated from the study-specific values. The parameter β_mean, in particular, is the parameter representing the “pooled” or “average” coefficient for arsenic dose that is a critical parameter in the extrapolation stage, where target-population risks are estimated. Additionally, the estimated power parameter (on the dose term) is not hierarchical, and the estimated value applied to both study-specific and pooled analyses. Prior probability distributions were assigned to the model parameters as shown in Table 4-1.

Table 4-1 Prior parameter values for dose-response meta-analyses

Parameter | Prior distribution
β(i)^a^ | Normal (β_mean, β_sigma)
β_mean | Gamma (a = 0.52, b = 1.12)
β_sigma | Half − Cauchy (scale = 5, location = 0)
power (q) | Half − Cauchy (scale = 0.315, location = 1)

a β(i) is the dose coefficient for data set i.

The gamma prior for β_mean reflects the determination that arsenic is causal for the health outcomes analyzed so that its coefficient in the model should not be negative. A sensitivity analysis using a more complex double Hill model that allows for negative response estimates was conducted to verify the reasonableness of this assumption (see Appendix C.1.1 [Sensitivity Analysis of Possible Nonmonotonic Dose-Response Relationships]). The specific choices for the values of the “a” and “b” parameters that define a gamma distribution are discussed in Allen et al. (2020b) and reflect the judgment that a relatively wide, uninformative prior (see below) should be used for the Bayesian modeling to represent the prior probability of both weak and strong associations between arsenic exposure and bladder cancer incidence. To represent this diffuse prior, a gamma distribution was selected such that the OR would be unlikely to be greater than 20 at a dose of 1 μg/kg-day (p < 0.01) and equally unlikely to be less than 1.0001 at that dose.^39^ Sensitivity analyses of this prior choice were conducted and show that alternative priors had no significant impact on the final results for any health outcome (see endpoint-specific subsections of Appendix C.1.2). The prior for the power parameter (q) restricts values for the parameter to obviate supra-linearity. Although the prior does place greatest prior probability for a power value of 1, the 95th percentile for the prior is 18, a very large value for the power that would almost completely flatten out the dose-response curve for low doses (i.e., make the logistic-power model essentially a threshold model). A prior for α*(i) is not needed; it is a function of β(i) and either the expected number in the referent group (for a cohort study) or the proportions of controls in the exposure groups (for a case-control study). Appendix C.1.1 (Bayesian Dose-Response Meta-Analysis Methods), defines those relationships and specifies the priors for those other parameters.

The key output of the dose-response meta-analyses—the posterior distribution for the “pooled” (average) value of the logistic slope and the power parameter—is used in lifetable calculations to estimate the U.S. population lifetime^40^ probability of observing a health outcome as a function of iAs dose (average μg/kg-day). The overall methodology is described by Allen et al. (2020a) and Allen et al. (2020b).^41^ Details of the lifetable calculations vary by health outcome and are discussed separately in the individual health outcome sections (see Sections 4.3.5 through 4.3.8). An important aspect of all the lifetable applications, however, is that the exposure scenario used posits a continuous, full lifetime exposure to a constant iAs dose, which includes a background U.S. iAs dose that is associated with the background U.S. risks estimated by the lifetables.

For each health outcome analyzed in Sections 4.3.5 through 4.3.8, the focus is on describing the relationship between U.S. lifetime extra risk above an estimate of the U.S. risk at a zero iAs dose and a full lifetime exposure to a constant iAs dose. Estimates for U.S. lifetime background probability of disease of 1.9% for bladder cancer and 5.7% for lung cancer were obtained from CDC lifetables. U.S. lifetime probability of disease of 40% for IHD (Lloyd-Jones et al., 1999),^42^ and 40% for diabetes (Gregg et al., 2014)^43^ were approximated from published rates due to the lack of lifetable data. The zero-dose U.S. lifetime risks were obtained by extrapolation, using the logistic slope and power estimates obtained from the dose-response meta-analysis and assuming that the U.S. lifetime background risks are associated with a background dose of 0.0365 μg iAs/kg-day (0.02 μg iAs/kg-day from dietary food consumption and 0.0165 μg iAs/kg-day from drinking water).^44^ This estimate of background dose is based on median estimates of intake for all ages and is not specific to any particular lifestage. The El-Masri-Kenyon PBPK model (El-Masri and Kenyon, 2008; El-Masri et al., 2018b; El-Masri et al., 2018a) indicates this level of U.S. background intake is consistent with the estimated 1–5 μg/L urinary background levels of total arsenic (summing inorganic, monomethyl, and dimethyl arsenic forms) that NRC (2013) considered to a reasonable for the U.S. population.

### 4.3.5 Bayesian Dose-Response Meta-Analysis Dose-Response Results for Bladder Cancer

Bayesian dose-response analyses for bladder cancer were conducted as previously described (see Sections 4.3.1 to 4.3.4, and Appendix C.1.1). As discussed in Section 4.3.2, dose-response meta-analyses were performed with estimates of low, maximum likelihood, and high doses to investigate dose conversion uncertainties. This section presents the results for dose-response meta-analyses using the MLE doses. The dose-response meta-analyses for bladder cancer included both case-control and cohort studies; the selected 11 studies, converted doses (low, MLE, high) and effective counts used in the bladder cancer dose-response meta-analyses are presented in Appendix C.1.2 (Bladder Cancer). See U.S. EPA (2025) for access to all dose-response input and output files for bladder cancer. U.S. EPA (2024b) provides a structured workflow and variable dictionary for the dose-response files.

A summary of the results of the bladder cancer dose-response meta-analyses using the MLE doses are presented in Table 4-2. The posterior mean for β_sigma is an estimate of the standard deviation of the study-specific β parameter estimates around the estimated mean, β_mean, and is therefore a measure of study-to-study heterogeneity with respect to that key parameter. The posterior mean for β_sigma is 1.35, and its 5th percentile is 0.76 (see Table 4-2). The mean coefficient of variation (CV), β_sigma/β_mean, is 3.7, indicating relatively high heterogeneity. This level of diversity across study slopes justifies the decision to model the slope parameters hierarchically (i.e., a study-specific, separate slope is derived for each study as opposed to estimating a single, common slope for all data sets). Appendix C.1.2 (Bladder Cancer; Summary of Bladder Cancer Dose-Response Meta-Analysis Results for MLE Dose Estimates) contains details of the modeling results, including posterior distribution plots for pooled and data-set-specific logistic slope parameters and nonhierarchical and hierarchical model plots for individual bladder cancer studies and sensitivity analyses (see Appendix C.1.2 Bladder Cancer Sensitivity Analyses).

Table 4-2 Summary of bladder cancer Bayesian analysis output, focusing on parameters important for risk estimation in the target population using MLE doses^a^

Parameter | Mean | Standard deviation | 5% | 95%
β_mean | 0.3694 | 0.3393 | 0.0041 | 1.0253
β_sigma | 1.3449 | 0.4828 | 0.7551 | 2.2474
β (Chen et al., 2010c) | 0.0807 | 0.2931 | 0.0362 | 0.1266
β (Steinmaus et al., 2013) | 0.4548 | 0.2956 | 0.2603 | 0.6572
β (Wu et al., 2013) | 2.9557 | 0.6416 | 2.1603 | 3.7522
β (Bates et al., 1995) | 0.4321 | 0.9917 | −1.8672 | 2.7721
β (Steinmaus et al., 2003) | −0.3131 | 0.8192 | −2.2484 | 1.4424
β (Bates et al., 2004) | −0.1572 | 0.3238 | −0.2956 | −0.0376
β (Meliker et al., 2010) | 0.1587 | 0.5518 | −0.8982 | 1.1941
β (Baris et al., 2016) | 0.9940 | 0.5744 | −0.0844 | 2.1180
β (Chang et al., 2016) | 0.0956 | 0.2930 | 0.0242 | 0.1735
β (Karagas et al., 2004) | 0.3369 | 0.9837 | −1.9864 | 2.6350
β (Michaud et al., 2004) | 0.5248 | 0.9568 | −1.6565 | 2.7972
power | 1.0890 | 0.0863 | 1.0050 | 1.2572

a Inference for Stan model: 4 chains, each with iter = 50,000; warmup = 37,500; thin = 1; post-warmup draws per

#### Extrapolation of Bladder Cancer Risk to Target Population

β_mean [the posterior distribution for the “pooled” (average) value of the logistic slope parameter] and power were used with U.S. all-cause mortality and bladder cancer incidence rates as input to a lifetable calculation of the lifetime probability of bladder cancer as a function of iAs dose (average μg/kg-day). Allen et al. (2020a) and Allen et al. (2020b) describe the methodology (along with Appendix C.1.1). The exposure scenario used for these extrapolations posits a continuous, full lifetime exposure to a constant iAs dose (including the U.S. background dose).

Age-specific U.S. background lifetable rates used in the analysis are provided in Appendix C.1.2 (Extrapolation of Bladder Cancer Extra Risk to Target U.S. Population). Application of the methods described in Section 4.3.4, using the pooled β_mean and power values derived from the bladder cancer dose-response meta-analysis and MLE dose estimates, results in the extra lifetime bladder cancer risks as a function of iAs dose (μg/kg-day) summarized in Table 4-3 and Figure 4-6. Table 4-3 represents the Bayesian hierarchical model estimation of the relationship between μg/kg-day dose and the risk above an estimate of a U.S. risk associated with a zero iAs dose. Table 4-3 presents lifetime extra risk values at various average daily iAs doses ranging from 0 μg/kg-day to 1.0 μg /kg-day, including 0.13 μg/kg-day, which is the total dose associated with roughly 10 μg/L iAs in drinking water exposure (the current iAs MCL), assuming a 0.011 L/kg-day mean U.S. water consumption rate (U.S. EPA (2019), and a 0.02 μg/kg-day U.S. median dietary background intake.

Table 4-3 Pooled dose-response meta-analysis estimates of extra lifetime bladder cancer incidence risk (per 10,000) at various average daily iAs doses using MLE doses^a,^ ^b^

Extra lifetime risk estimates (per 10,000)^a^ | Average inorganic arsenic dose (μg/kg-d)^b^
Extra lifetime risk estimates (per 10,000)^a^ | 0 | 0.0365 | 0.06 | 0.1 | 0.13^c^ | 0.2 | 0.3 | 0.4 | 0.5 | 0.6 | 0.7 | 0.8 | 0.9 | 1.0
5th % | 0 | 0.002 | 0.04 | 0.06 | 0.08 | 0.13 | 0.21 | 0.29 | 0.36 | 0.44 | 0.53 | 0.61 | 0.69 | 0.78
Mean | 0 | 1.96 | 3.36 | 5.88 | 7.87^d^ | 12.80 | 20.50 | 29.00 | 38.32 | 48.53 | 59.72 | 72.00 | 85.47 | 100.28
95th % | 0 | 5.66 | 9.61 | 16.76 | 22.4 | 36.66 | 59.36 | 85.09 | 114.35 | 147.57 | 184.38 | 225.41 | 272.16 | 324.20

a Extra lifetime risks are presented as mean risk with 5%–95% probabilities based on mean, 5% and 95% estimates of dose-response slopes.

b Doses used in EPA modeling. U.S. daily background dose is estimated at 0.0365 μg/kg-day, 0.02 μg/kg-day from diet, 0.0165 μg/kg-day from water and 0 μg/kg-day from air (see Section 4.3.4).

c Daily intake associated with the current MCL of 10 μg/L drinking water assuming 0.011 L/kg-day water consumption rate and 0.02 μg/kg-day from diet.

d Lifetime extra risks are presented in terms of risk per 10,000 in this table to contextualize the risks in a hypothetical U.S. cohort of 10,000 individuals exposed for a lifetime. A lifetime risk of 7.87 per 10,000 is equivalent to a risk of 0.000787. This illustrative and contextual presentation is not intended to represent a threshold for adversity or recommended risk or action level.

Figure 4-6 U.S. bladder cancer lifetime extra risk versus μg/kg-day iAs doses for doses up to 1.0 μg/kg-day (top plot) and doses up to 0.2 μg/kg-day (bottom plot)

The polynomial and linear trendline formulas given in Figure 4-6 are provided for convenience in approximating a lifetime extra risk at doses and exposures other than those presented in Table 4-3^45^. The slope of the linear trendline for the upper confidence limit (i.e., 95% upper bound on risk; UCL) on the extra risk associated with dose above background is analogous to the traditional EPA cancer slope factor (CSF).^46^ Although EPA’s modeling approach in this assessment does not assume linearity in response, a linear trendline slope (1.76 × 10⁻^2^ per μg/kg-day) was provided as the CSF below 0.2 μg/kg-day. Mendez et al. (2017) reports that the 95th percent upper bound on drinking water concentrations in the United States is 15.4 μg/L, which translates to approximately 0.19 μg/kg-day iAs daily intake using a 0.011 L/kg-day water consumption rate and accounting for 0.02 μg/kg-day daily iAs exposure via the diet. Therefore, the provided linear CSF below this daily dose covers the majority of drinking water exposure scenarios in the United States. The CSF only provides approximations of the upper-bound lifetime extra risks explicitly calculated using the lifetable approach and using the CSF can result in overestimates of the lifetable risks approximately 20% at very low doses (i.e., 0.005–0.01 μg/kg-day). Given the nonlinearity in upper-bound lifetime extra risks, linear trendlines beyond 0.2 μg/kg-day are associated with increasingly imprecise estimates. For example, a linear trendline up to 0.4 μg/kg-day confers overestimates of risk exceeding 30% at low doses. To account for potential needs to estimate lifetime risks at doses greater than 0.2 μg/kg-day, a polynomial trendline (risk = 0.0184x^2^ + 0.0137x, where x = dose) is also provided for daily intakes of up to 1.0 μg/kg-day. This polynomial trendline provides more precise approximations of lifetable-calculated lifetime risks, with underestimates of low-dose risk of less than 10%. This polynomial trendline is appropriate for the estimation of risks at doses up to 1.0 μg/kg-day. Table C-31 also provides lifetable-calculated risks at daily intakes of 0 μg/kg-day to 1.5 μg/kg-day, at increments of 0.005 μg/kg-day (i.e., mean and 95% upper-bound lifetime extra risk values are reported for 300 daily intake values). Users that need to generate exact mean or upper-bound lifetime extra risk values at daily intakes other than those reported in Table C-31 can use the Bayesian logistic-power modeling results and lifetable R codes (U.S. EPA, 2025). See the structured workflow, outline, and variable dictionary (U.S. EPA, 2024b) for documentation of modeling files.

#### Summary of Dose-Response Meta-Analysis of Bladder Cancer Studies

Prior to the modeling the data, the reported exposures from the included studies were converted to estimates of lifetime daily doses of total inorganic arsenic in units of average daily μg iAs per kg body weight (μg/kg-day). Uncertainties in average exposures for the exposure groups and in the conversion to average μg/kg-day daily doses were accounted for, as described in Section 4.3.2. The reported counts of cases (and controls in the instance of case-control studies) were adjusted to account for the effect of covariates. See Appendix C.1.1 (Treatment of Dose Uncertainty; and Adjusting for Covariates) for details.

Following those adjustments, the dose-response meta-analysis approach described in Section 4.3.4 was applied to a set of 11 data sets. On the basis of visual inspection, the model fit was considered adequate for all but one dataset.^47^ The high dose was dropped to obtain adequate fit for the Steinmaus et al. (2013) dataset because confidence bounds for at least one dose group were outside of the 90% confidence bounds for the dose-response meta-analysis modeling results (see Appendix C.1.2 [Bladder Cancer; Summary of Bladder Cancer Dose-Response Meta-Analysis Results for MLE Dose Estimates]). The choice of a hierarchical structure was supported by the relatively large variation (with mean estimated CV of about 3.7) estimated by the dose-response meta-analysis. The mean of the posterior distribution for β_mean (using the MLE dose estimates) was 0.37 (90% credible interval,^48^ 0.004 to 1.03) per μg/kg-day, with an estimated power parameter of 1.09 (95% credible interval, 1.002 to 1.317).

The full β_mean and power parameter posteriors were used to derive a posterior distribution of U.S.-specific lifetime extra-risk estimates via a lifetable analysis using U.S. all-cause mortality and U.S. bladder cancer incidence rates as summarized in Appendix C.1.2 (Extrapolation of Bladder Cancer Risk to Target Population) and in Allen et al. (2020a) and Allen et al. (2020b). As shown in Table 4-3, these U.S.-specific lifetime extra risk estimates were derived for various exposure scenarios (assuming daily intake levels of 0–1.0 μg/kg-day, approximately equivalent to U.S. water iAs exposures of 0–89 μg/ L). At 0.0365 μg/kg-day (estimated background exposure), the mean of the extra lifetime risk distribution was 1.96 per 10,000 (90% credible interval, 0.002 to 5.6 per 10,000). At 0.13 μg/kg-day (daily intake at the current MCL of 10 μg/L), the mean extra lifetime risk was 7.87 per 10,000 (90% credible interval, 0.08 to 22.4 per 10,000).

The above estimates were derived using the MLE doses estimated for study participants. The effect of the uncertainty in those dose values was examined, combining the uncertainty in the means for the exposure-defined groups and in the conversions necessary to obtain a common metric, average μg/kg-day (see Appendix C.1.2 [Bladder Cancer Sensitivity Analyses]). The effect was minimal overall: keeping the estimated power parameter value constant at 1.089, the pooled logistic slope changed from 0.3642^49^ to 0.3950 (using systematically lower dose values consistent with the level of uncertainty) or 0.3267 (using systematically higher dose values consistent with the level of uncertainty). The low-end and high-end dose values resulting from a combination of various factors indicate the results are not sensitive to variability/uncertainties in the exposure factors used to estimate the dose levels.

Other sensitivity analyses performed for the bladder cancer dose-response meta-analysis investigated the potential impact of alternative gamma prior distributions for β _mean, the inclusion of a background inhalation exposure, the use of urine biomarker studies, the use of alternative exposure metrics or lagged analyses within studies and omitting individual data sets from the analysis (see Appendix C.1.2 [Bladder Cancer Sensitivity Analyses). The sensitivity analysis examining the impact of different gamma prior distributions for β_mean did not result in large differences (≤ 17%; see Appendix C.1.2, Table C-29) in the posterior distributions of the β_mean parameter, indicating that the choice of gamma prior does not substantially influence the estimated association between iAs exposure and bladder cancer in this dose-response meta-analysis. Incorporation of estimates of inhalation exposures in the background estimate of total exposure also did not result in dramatically different (≤0.5%) estimates of extra risk. Consideration of a larger daily background exposure (0.11 μg/kg-day) also had minimal impact on estimated lifetime extra risks at the drinking water standard, only decreasing lifetime extra risks by 4.3%, indicating the lifetable methods used in the assessment are relatively insensitive to the estimates of U.S. background iAs exposure.

When both urine studies are excluded, the mean logistic slope decreased by 59%. This result indicates that the urinary biomarker studies are important drivers of the overall estimated association between iAs exposure and bladder cancer in this dose-response meta-analysis.

Baris et al. (2016) presented multiple results in their study using either total mg or μg/day as the exposure metric and analyses lagged 40 years or unlagged. Table C-30 shows consideration of these alternative data sets in the dose-response meta-analysis did not substantially influence the final modeling; the greatest difference was a 26% decrease in the estimated logistic slope when the 40-year lagged mg exposure metric was used from the Baris study.

Consideration of a normal prior distribution for the pooled slope parameter instead of the gamma distribution (which constrains estimated slope values to be positive) resulted in an increase in mean lifetime extra risks of 14% and 18% at 0.0365 μg/kg-day and 0.13 μg/kg-day daily iAs intake. Use of the logistic model (i.e., power = 1) vs. the logistic-power model resulted in similar increases in lifetime extra risks.

Finally, the influence of the individual studies on the dose-response meta-analysis result (see Table C-28) were tested. With one exception, the effect of removing single studies from the analysis was minimal, with β_mean values differing by less than 20%. The exception was the case-control study of Wu et al. (2013), which is not surprising as this study has the strongest low-dose association between iAs exposure and bladder cancer incidence. In this case, the removal of that study reduced the mean and upper bound β_mean slope estimates by approximately 68%.

In summary, inclusion of a background inhalation exposure had the least (≤0.5%) impact on the β_mean logistic slope estimates for bladder cancer. Exclusion of Wu (68%) or both urinary studies (59%) of urinary biomarker studies would have the greatest impact on the β_mean logistic slope estimates for bladder cancer. The bladder cancer β_mean logistic slope estimates were moderately impacted by exclusion of other studies (≤20%), the Baris et al. (2016) study metric selected (≤30%), variability/uncertainties in the exposure factors (≤16%), alternative gamma prior distributions (≤16%), or using a normal prior for bmean or the logistic model (≤18%).

### 4.3.6 Bayesian Dose-Response Meta-Analysis Dose-Response Results for Lung Cancer

Bayesian dose-response analyses for lung cancer were conducted as previously described (see Sections 4.3.1 to 4.3.4 and Appendix C.1.1). As discussed in Section 4.3.2, dose-response meta-analyses were performed with low, maximum likelihood, and high dose estimates to investigate dose conversion uncertainties. This section presents the results for dose-response meta-analyses using the MLE doses. The dose-response meta-analyses for lung cancer included both case-control and cohort studies; the six selected studies, converted doses (low, MLE, high) and effective counts used in the lung cancer dose-response meta-analyses are presented in Appendix C.1.2 (Oral Lung Cancer). See U.S. EPA (2025) for access to all dose-response input and output files for lung cancer. U.S. EPA (2024b) provides a structured workflow and variable dictionary for the dose-response files.

In this section, a summary of the results of the lung cancer dose-response meta-analyses using the MLE doses is presented in Table 4-4. The posterior mean for β_sigma is an estimate of the standard deviation of the study-specific β parameter estimates around the estimated mean, β_mean, and is therefore a measure of study-to-study heterogeneity with respect to that key parameter. The posterior mean for β_sigma is 0.313, and its 5th percentile is 0.093 (see Table 4-4). This is associated with a mean coefficient of variation (CV), β_sigma/β_mean, of about 2.08, indicating moderately high heterogeneity. This level of diversity across study slopes justifies the decision to model the slope parameters hierarchically (i.e., a separate slope is derived for each study as opposed to estimating a single, common slope for all data sets). Appendix C.1.2 (Oral Lung Cancer) contains details of the modeling results, including posterior distribution plots for pooled and data-set-specific logistic slope parameters and nonhierarchical and hierarchical model plots for individual studies (see Appendix C.1.2 Oral Lung Cancer; Summary of Lung Cancer Dose-Response Meta-Analysis Results for MLE Dose Estimates) and sensitivity analyses (see Appendix C.1.2 Lung Cancer Sensitivity Analyses).

Table 4-4 Summary of lung cancer (oral exposure) Bayesian analysis output using MLE doses^a^

Parameter | Mean | Standard deviation | 5% | 95%
β_mean | 0.1543 | 0.1329 | 0.0040 | 0.4016
β_sigma | 0.3172 | 0.2117 | 0.0933 | 0.7078
β (Argos et al., 2014) | 0.0164 | 0.0113 | −0.0007 | 0.0360
β (García-Esquinas et al., 2013) | 0.3542 | 0.3689 | −0.1115 | 1.0615
β (Chen et al., 2010a) | 0.0305 | 0.0114 | 0.0123 | 0.0496
β (Dauphiné et al., 2013) | 0.1332 | 0.1809 | −0.1578 | 0.4401
β (Ferreccio et al., 2000) | 0.5003 | 0.185 | 0.1991 | 0.8111
β (Steinmaus et al., 2013) | 0.1043 | 0.028 | 0.0573 | 0.1493
power | 1.0959 | 0.0930 | 1.0053 | 1.2788

a Inference for Stan model: 4 chains, each with iter = 50,000; warmup = 37,500; thin = 1; post-warmup draws per chain = 12,500, total post-warmup draws = 50,000.

#### Extrapolation of Lung Cancer Risk to Target Population

The posterior distribution for the “pooled” (average) value of the logistic slope parameter, β_mean, and power parameter were used with U.S. all-cause mortality and lung cancer incidence rates as input to a lifetable calculation of the lifetime probability of lung cancer as a function of iAs dose (average μg/kg-day including background levels of U.S. exposure). The methodology is presented in Allen et al. (2020a) and Allen et al. (2020b) and in Appendix C.1.1. The exposure scenario used for these extrapolations posits a continuous, full lifetime exposure to a constant iAs dose.

Age-specific lifetable rates used in the analysis are provided in Appendix C.1.2 (Extrapolation of Lung Cancer Extra Risk to Target U.S. Population). Application of the methods described in Section 4.3.4, using the pooled β_mean values derived from the lung cancer dose-response meta-analysis and MLE dose estimates, results in the extra lifetime cancer risks as a function of iAs dose (μg/kg-day) summarized in Table 4-5 and Figure 4-7. Table 4-5 represents the Bayesian hierarchical model estimation of the relationship between μg/kg-day dose and the risk above an estimate of a U.S. risk associated with a zero iAs dose. Table 4-5 presents lifetime extra risk values at various average daily iAs doses ranging from 0 μg/kg-day to 1.0 μg/kg-day, including 0.13 μg/kg-day, which is the total dose associated with roughly 10 μg/L iAs in drinking water exposure (the current iAs MCL), assuming a 0.011 L/kg-day mean U.S. water consumption rate (U.S. EPA (2019), and a 0.02 μg/kg-day U.S. median dietary background intake.

Table 4-5 Pooled dose-response meta-analysis estimates of extra lifetime lung cancer incidence risk (per 10,000) at various average daily iAs doses

Extra lifetime risk estimates (per 10,000)^a^ | Average inorganic arsenic dose (μg/kg-d)^b^
Extra lifetime risk estimates (per 10,000)^a^ | 0 | 0.0365^b^ | 0.06 | 0.1 | 0.13^c^ | 0.2 | 0.3 | 0.4 | 0.5 | 0.6 | 0.7 | 0.8 | 0.9 | 1.0
5th % | 0 | 0.06 | 0.10 | 0.18 | 0.25 | 0.40 | 0.62 | 0.85 | 1.09 | 1.34 | 1.60 | 1.85 | 2.11 | 2.37
Mean | 0 | 2.56 | 4.36 | 7.56 | 10.05^d^ | 16.09 | 25.20 | 34.79 | 44.83 | 55.31 | 66.23 | 77.58 | 89.37 | 101.61
95th % | 0 | 7.17 | 12.08 | 20.72 | 27.42 | 43.68 | 68.32 | 94.16 | 121.51 | 150.35 | 180.48 | 212.14 | 245.11 | 279.69

a Extra lifetime risks are presented as mean risk with 5%–95% probabilities based on mean, 5% and 95% estimates of dose-response slopes.

b Doses used in EPA modeling. U.S. daily background dose is estimated at 0.0365 μg/kg-day, 0.02 μg/kg-day from diet, 0.0165 μg/kg-day from water and 0 μg/kg-day from air (see Section 4.3.4).

c Daily intake associated with the current MCL of 10 μg/L drinking water assuming 0.011 L/kg-day water consumption rate and 0.02 μg/kg-day from diet.

d Lifetime extra risks are presented in terms of risk per 10,000 in this table to contextualize the risks in a hypothetical U.S. cohort of 10,000 individuals exposed for a lifetime. A lifetime risk of 10.05 per 10,000 is equivalent to a risk of 0.001005. This illustrative and contextual presentation is not intended to represent a threshold for adversity or recommended risk or action level.

Figure 4-7 U.S. lung cancer lifetime extra risk versus μg/kg-day iAs doses for doses up to 1.0 μg/kg-day (top plot) and doses up to 0.2 μg/kg-day (bottom plot)

The polynomial and linear trendline formulas given in Figure 4-7 are provided for convenience in approximating a lifetime extra risk at doses and exposures other than those presented in Table 4-5^50^. The slope of the linear trendline for the upper confidence limit (i.e., 95% upper bound on risk, UCL) on the extra risk associated with dose above background is analogous to the traditional EPA cancer slope factor (CSF).^51^ Although EPA’s modeling approach in this assessment does not assume linearity in response, a linear trendline slope (2.13 × 10⁻^2^ per μg/kg-day) was provided as the CSF below 0.2 μg/kg-day (see Section 4.3.5 for the rationale for this cut-off value). The CSF only provides approximations of the upper-bound lifetime extra risks explicitly calculated using the lifetable approach and use of the CSF can result in overestimates of the lifetable risks exceeding 15% at very low doses (e.g., 0.005 μg/kg-day). Given the nonlinearity in lifetime extra risks, linear trendlines beyond 0.2 μg/kg-day are associated with increasingly imprecise estimates. For example, a linear trendline up to 0.4 μg/kg-day confers overestimates of risk exceeding 20% at low doses. To account for the need to estimate lifetime risks at doses greater than 0.2 μg/kg-day, a polynomial trendline (risk = 0.0074x^2^ + 0.0206x, where x = dose) is also provided for daily intakes of up to 1.0 μg/kg-day. This polynomial trendline provides more precise approximations of lifetable-calculated lifetime risks, with overestimates of low-dose risk of approximately 10%. This polynomial trendline is appropriate for the estimation of risks at doses up to 1.0 μg/kg-day. Table C-41 also provides lifetable-calculated risks at daily intakes of 0 μg/kg-day to 1.5 μg/kg-day, at increments of 0.005 μg/kg-day (i.e., mean and 95% upper bound lifetime extra risk values are reported for 300 daily intake values). Users that need to generate exact mean or upper-bound lifetime extra risk values at daily intakes other than those reported in Table C-41 can use the Bayesian logistic-power modeling results and lifetable R codes (U.S. EPA, 2025). See the structured workflow, outline, and variable dictionary (U.S. EPA, 2024b) for documentation of modeling files.

#### Summary of Dose-Response Meta-Analysis of Lung Cancer Studies (Oral Exposure)

Prior to the analysis, the reported exposures from the included studies were converted to estimates of lifetime daily doses of total inorganic arsenic in units of average daily μg iAs per kg body weight (μg/kg-day). Uncertainties in average exposures for the exposure groups and in the conversion to average μg/kg-day doses were accounted for, as described in Section 4.3.2. The reported counts of cases (and controls in the instance of case-control studies) also were adjusted to account for the effect of covariates.

Given those adjustments, the dose-response meta-analysis approach described in Section 4.3.4 was applied to six data sets. On the basis of visual inspection, the model fit was considered adequate for all but one dataset. The high dose was dropped to obtain adequate fit for the Ferreccio et al. (2000) dataset because confidence bounds for at least one dose group were outside of the 90% confidence bounds for the dose-response meta-analysis modeling results (see Appendix C.1.2 [Summary of Lung Cancer Dose-Response Meta-Analysis Results for MLE Dose Estimates]). The choice of a hierarchical structure was supported by the moderately large variation (with mean estimated CV of about 2.3) estimated by the dose-response meta-analysis. The mean of the posterior distribution for β_mean (using the MLE doses) was 0.1543 (90% credible interval, 0.004 to 0.4016) per μg/kg-day, with an estimated power parameter of 1.0959 (95% credible interval: 1.0026 to 1.3387).

The full β_mean and power parameter posteriors (using the MLE doses) were used to derive a posterior distribution of U.S.-specific lifetime extra-risk estimates via a lifetable analysis using U.S. all-cause mortality and U.S. lung cancer incidence rates as summarized in Appendix C.1.2 (Extrapolation of Lung Cancer Risk to Target U.S. Population) section. As shown in Table 4-5, these U.S.-specific lifetime extra risk estimates were derived for various exposure scenarios incorporating background iAs exposure (assuming daily intake levels of 0–1.0 μg/kg-day, approximately equivalent to U.S. water iAs exposures of 0–89 μg/L). At 0.0365 μg/kg-day (estimated background exposure), the mean of that extra lifetime risk distribution was 2.56 per 10,000 (90% credible interval, 0.06 to 7.17 per 10,000). At 0.13 μg/kg-day (daily intake at the current MCL of 10 μg/L), the mean extra lifetime risk was 10.1 per 10,000 (90% credible interval, 0.25 to 27.42 per 10,000).

The above estimates were derived using the MLE doses for study participants. The effect of the uncertainty in those dose values was examined, combining the uncertainty in the means for the exposure-defined groups and in the conversions necessary to obtain a common metric, average μg/kg-day. The effect was minimal overall: keeping the estimated power parameter value constant at 1.0959, the pooled logistic slope changed from 0.1522^52^ to 0.1989 (an increase of 31% using systematically lower dose values consistent with the level of uncertainty) or 0.1161 (a decrease of 24% using systematically higher dose values consistent with the level of uncertainty). This finding indicates that the results are not overly sensitive to variability/uncertainties in the exposure factors used to estimate the dose levels.

Other sensitivity analyses performed for the lung cancer dose-response meta-analysis investigated the potential impact of alternative gamma prior distributions for β _mean, the inclusion of a background inhalation exposure, the use of urine biomarker studies, and omitting individual data sets from the analysis (see Appendix C.1.2 [Lung Cancer Sensitivity Analyses]). The sensitivity analysis examining the impact of different gamma prior distributions for β_mean did not result in major differences in the posterior distributions of the β_mean parameter (≥15%, see Appendix C.1.2, Table C-40). Incorporation of estimates of inhalation exposures in the background estimate of total exposure also did not result in appreciable different estimates of extra risk (≥0.2%). Consideration of a larger daily background exposure (0.11 μg/kg-day) also had minimal impact on estimated lifetime extra risks at the drinking water standard, only decreasing lifetime extra risks by 1.8%, indicating the lifetable methods used in the assessment are relatively insensitive to the estimates of U.S. background iAs exposure.

Excluding the two urine studies increased the mean logistic slope by approximately 10%. The two studies influenced the analysis in opposite directions, with the exclusion of Argos et al. (2014) increasing the slope by 35% and the exclusion of García-Esquinas et al. (2013) decreasing the slope by 18%. These results indicate that the urinary biomarker studies are not substantial drivers of the overall estimated association between iAs exposure and lung cancer in this dose-response meta-analysis.

Consideration of a normal prior distribution for the pooled slope parameter instead of the gamma distribution (which constrains estimated slope values to be positive) resulted in an increase in mean lifetime extra risks of 35% and 34% at 0.0365 μg/kg-day and 0.13 μg/kg-day daily iAs intake. Use of the logistic model (i.e., power = 1) vs. the logistic-power model resulted in similar increases in lifetime extra risks.

Finally, the influence of the individual studies on the dose-response meta-analysis result (see Appendix C.1.2, Table C-39) were tested. Across most included studies, the effect of removing single studies from the analysis was minimal to moderate, with changes to the β_mean logistic slope not exceeding 35%. The study that influenced the analysis the most (i.e., its removal changed the pooled estimate of the β_mean parameter the most) was the data set from the Ferreccio study. In this case, the removal of the study reduced the mean of the β parameter by 65%.

In summary, inclusion of a background inhalation exposure had the least (≤0.4%) impact on the β_mean logistic slope estimates for lung cancer. Study selection has the potential to have the greatest (≤65%) impact on the β_mean logistic slope estimates for lung cancer. The lung cancer β_mean logistic slope estimates were moderately impacted by variability/uncertainties in the exposure factors (≤31%), alternative gamma prior distributions (≤15%), the use of urine biomarker studies (≤10%) or using a normal prior for bmean or the logistic model (≤35%).

### 4.3.7 Bayesian Dose-Response Meta-Analysis Dose-Response Results for IHD

Bayesian dose-response analyses for IHD were conducted as previously described (see Sections 4.3.1 to 4.3.4 and Appendix C.1.1). As discussed in Section 4.3.2, EPA performed dose-response meta-analyses with low, maximum likelihood, and high dose estimates to investigate dose conversion uncertainties. This section presents the results for dose-response meta-analyses using the MLE doses. The dose-response meta-analyses for IHD included both case-control and cohort studies. Appendix C.1.2 (Ischemic Heart Disease [IHD] Incidence) describes the selected studies, converted doses (low, MLE, high), and effective counts used in the IHD dose-response meta-analyses, detailed modeling results using MLE doses, and sensitivity analyses. See U.S. EPA (2025) for access to all dose-response input and output files for IHD. U.S. EPA (2024b) provides a structured workflow and variable dictionary for the dose-response files.

Table 4-6 presents summary results for the IHD analysis, using the MLE doses. The posterior mean for β_sigma is an estimate of the standard deviation of the study-specific β parameter estimates around the estimated mean, β_mean, and is therefore a measure of study-to-study heterogeneity with respect to that key parameter. The posterior mean for β_sigma is 0.4652, and its 5th percentile is 0.087 (see Table 4-6). This is associated with a mean coefficient of variation (CV), β_sigma/β_mean, of about 1.78, indicating moderately high heterogeneity. This level of diversity across study slopes justifies the decision to model the slope parameters hierarchically (i.e., a separate slope is derived for each study as opposed to estimating a single, common slope for all data sets). Appendix C.1.2 (Summary of IHD Dose-Response Meta-Analysis Results for MLE Dose Estimates) contains details of the modeling results, including posterior distribution plots for pooled and data-set-specific logistic slope parameters and nonhierarchical and hierarchical model plots for individual studies and sensitivity analyses (see Appendix C.1.2 [IHD Sensitivity Analyses]).

Table 4-6 Summary of Bayesian analysis output for IHD, focusing on key parameters for risk estimation in the target population using MLE doses^a^

Parameter | Mean | Standard deviation | 5% | 95%
β_mean | 0.2602 | 0.2157 | 0.0096 | 0.6679
β_sigma | 0.4652 | 0.392 | 0.0870 | 1.1798
(Chen et al., 2013c) | 0.0298 | 0.0157 | 0.0062 | 0.0572
(James et al., 2015) | 0.7194 | 0.5394 | 0.0404 | 1.7505
(Moon et al., 2013) | 0.4113 | 0.2154 | 0.0701 | 0.7780
(Wu et al., 2010b) | 0.1564 | 0.0732 | 0.0416 | 0.2819
(Wade et al., 2015) | 0.3614 | 0.2002 | 0.0640 | 0.7165
power | 1.1191 | 0.1133 | 0.10068 | 1.3438

a Inference for Stan model: 4 chains, each with iter = 50,000; warmup = 37,500; thin = 1; post-warmup draws per chain = 12,500, total post-warmup draws = 50,000.

#### Extrapolation of IHD Risk to Target U.S. Population

Because information on IHD rates across age groups is not available to populate a lifetable, the posterior distribution for the “pooled” (average) value of the logistic slope parameter, β_mean, along with the power parameter, was used with a summary value for the U.S. lifetime probability of developing IHD to estimate the lifetime probability developing IHD as a function of iAs dose (average μg/kg-day, including estimated background iAs intake). The methodology is described by Allen et al. (2020a) and Allen et al. (2020b). The exposure scenario used for these extrapolations posits a continuous, full lifetime exposure to a constant (i.e., daily) iAs dose. The IHD background lifetime probabilities used in the analyses are estimated to be 40% (Lloyd-Jones et al., 1999).^53^

Using the β_mean values derived for the MLE set of dose estimates from the studies selected for the dose-response meta-analyses results in extra lifetime IHD risks as a function of iAs dose (μg/kg-day), summarized in Table 4-7 and Figure 4-8. Table 4-7 represents the Bayesian hierarchical model estimation of the relationship between μg/kg-day dose and the risk above an estimate of a U.S. risk associated with a zero iAs dose. Table 4-7 presents lifetime extra risk values at various average daily iAs doses ranging from 0 μg/kg-day to 1.0 μg/kg-day, including 0.13 μg/kg-day, which is the total dose associated with roughly 10 μg/L iAs in drinking water exposure (the current iAs MCL), assuming a 0.011 L/kg-day mean U.S. water consumption rate (U.S. EPA (2019), and a 0.02 μg/kg-day U.S. median dietary background intake.

Table 4-7 Pooled dose-response meta-analysis estimates of extra lifetime IHD risk (per 10,000) at various average daily iAs doses using MLE doses^a,^ ^b^

Extra lifetime risk estimates (per 10,000)^a^ | Average inorganic arsenic dose (μg/kg-d)^b^
Extra lifetime risk estimates (per 10,000)^a^ | 0 | 0.1 | 0.13^c^ | 0.2 | 0.3 | 0.4 | 0.5 | 0.6 | 0.7 | 0.8 | 0.9 | 1.0
5th % | 0 | 2.70 | 3.68 | 6.05 | 9.70 | 13.54 | 17.46 | 21.54 | 25.64 | 29.86 | 34.11 | 38.41
Mean | 0 | 82.50 | 109.96^d^ | 176.57 | 276.42 | 380.50 | 487.94 | 598.16 | 710.68 | 825.11 | 941.11 | 1058.35
95th % | 0 | 219.24 | 290.59 | 462.42 | 719.83 | 988.38 | 1262.91 | 1546.94 | 1836.55 | 2131.07 | 2431.59 | 2733.85

a Extra lifetime risks are presented as mean risk with 5%–95% probabilities based on mean, 5% and 95% estimates of dose-response slopes.

b Doses used in EPA modeling. U.S. daily background dose is estimated at 0.0365 μg/kg-day, 0.02 μg/kg-day from diet, 0.0165 μg/kg-day from water and 0 μg/kg-day from air (see Section 4.3.4).

c Daily intake associated with the current MCL of 10 μg/L drinking water assuming 0.011 L/kg-day water consumption rate and 0.02 μg/kg-day from diet.

d Lifetime extra risks are presented in terms of risk per 10,000 in this table to contextualize the risks in a hypothetical U.S. cohort of 10,000 individuals exposed for a lifetime. A lifetime risk of 109.96 per 10,000 is equivalent to a risk of 0.010996. This illustrative and contextual presentation is not intended to represent a threshold for adversity or recommended risk or action level.

Figure 4-8 U.S. IHD lifetime extra risk versus μg/kg-day MLE doses for all doses. See Section 4.3.4 for discussion of 0.0365 μg/kg-day U.S. background dose estimate

The polynomial trendline formulas given in Figure 4-8 are provided for convenience in approximating a lifetime extra risk at doses and exposures other than those presented in Table 4-7^54^. The polynomial trendline for the upper-bound lifetime extra risks (risk = 0.0459x^2^ + 0.2289x, where x = dose) only provide an approximation of the upper-bound lifetime extra risks explicitly calculated using the lifetable approach and use of the trendline can result in overestimates of the lifetable risks exceeding 15% at very low doses (e.g., 0.005 μg/kg-day). This polynomial trendline is appropriate for the estimation of risks at doses up to 1.0 μg/kg-day. Table C-59 also provides lifetable-calculated risks at daily intakes above the RfD, from 0.065 μg/kg-day to 1.5 μg/kg-day, at increments of 0.005 μg/kg-day (i.e., mean and 95% upper-bound lifetime extra risk values are reported for >280 daily intake values). Users that need to generate exact mean or upper-bound lifetime extra risk values at daily intakes other than those reported in Table C-59 can use the Bayesian logistic-power modeling results and lifetable R codes (U.S. EPA, 2025). See the structured workflow, outline, and variable dictionary (U.S. EPA, 2024b) for documentation of modeling files.

#### Summary of Dose-Response Meta-Analysis of IHD Studies

General limitations and uncertainties associated with the studies used in the IHD dose-response meta-analyses were discussed in Section 4.3.1. As for the bladder cancer and lung cancer dose-response meta-analyses, the exposure information from studies used in the dose-response meta-analyses were converted to estimates of lifetime daily doses of total iAs in units of average μg iAs per kg body weight (μg/kg-day). Uncertainties in average lifetime daily doses for the exposure groups and in the conversion to μg/kg-day were accounted for, as described in Section 4.3.2, and the reported counts of cases (and controls in the instance of case-control studies) were adjusted to account for the effect of covariates (see Appendix C.1.1 [Treatment of Dose Uncertainty] and Appendix C.1.1 [Adjusting for Covariates] for details).

Following those adjustments, the dose-response meta-analysis approach described in Section 4.3.4 was applied to a set of five data sets. On the basis of visual inspection, the model fit was considered adequate for all but one dataset. The high dose was dropped to obtain adequate fit for the Wu et al. (2010b) dataset because confidence bounds for at least one dose group were outside of the 90% confidence bounds for the dose-response meta-analysis modeling results (see Appendix C.1.2 [Summary of IHD Dose-Response Meta-Analysis Results for MLE Dose Estimates]). The choice of a hierarchical structure was supported by the relatively large variation (with mean estimated CV of about 1.7) estimated by the dose-response meta-analysis. The mean of the posterior distribution for β_mean (using the MLE dose estimates) was 0.26 (90% credible interval,^55^ 0.01 to 0.67) per μg/kg-day, with an estimated power parameter of 1.12 (95% credible interval, 1.003 to 1.42).

The full β_mean and power parameter posteriors were used to derive a posterior distribution of U.S.-specific lifetime extra-risk estimates via a lifetable analysis using a summary value for the U.S. lifetime probability of developing IHD as summarized in Appendix C.1.2 (Ischemic Heart Disease (IHD); Extrapolation to Targe U.S. Population) section and by Allen et al. (2020a) and Allen et al. (2020b). As shown in Table 4-7, these U.S.-specific lifetime extra risk estimates were derived for various exposure scenarios (assuming daily intake levels of 0–1.0 μg/kg-day, approximately equivalent to U.S. water iAs exposures of 0–89 μg/L). At 0.13 μg/kg-day (daily intake at the current MCL of 10 μg/L), the mean extra lifetime risk was 110 per 10,000 (90% credible interval, 3.7 to 290.6 per 10,000).

The above estimates were derived using the MLE doses estimated for study participants. The effect of the uncertainty in those dose values was examined, combining the uncertainty in the means for the exposure-defined groups and in the conversions necessary to obtain a common metric, average μg/kg-day (see Appendix C.1.2 [ IHD Sensitivity Analyses]). The effect was minimal overall: keeping the estimated power parameter value constant at 1.1191, the pooled logistic slope changed from 0.2545^56^ to 0.2418 (5% decrease using systematically lower dose values consistent with the level of uncertainty) or 0.2001 (21% decrease using systematically higher dose values consistent with the level of uncertainty). The low-end and high-end dose values resulting from a combination of various factors indicate the results are not overly sensitive to variability/uncertainties in the exposure factors used to estimate the dose levels.

Other sensitivity analyses performed for the bladder cancer dose-response meta-analysis investigated the potential impact of alternative gamma prior distributions for β mean, the inclusion of a background inhalation exposure, the use of urine biomarker studies, and omitting individual data sets from the analysis. The sensitivity analysis examining the impact of different gamma prior distributions for β_mean did not result in large differences (≤12%; see Appendix C.1.2, Table C-58) in the posterior distributions of the β_mean parameter, indicating that the choice of gamma prior does not substantially influence the estimated association between iAs exposure and IHD in this dose-response meta-analysis. Incorporation of estimates of inhalation exposures in the background estimate of total exposure also did not result in appreciably different estimates of extra risk (≤0.2%). Consideration of a larger daily background exposure (0.11 μg/kg-day) also had minimal impact on estimated lifetime extra risks at the drinking water standard, only decreasing lifetime extra risks by 1.7%, indicating the lifetable methods used in the assessment are relatively insensitive to the estimates of U.S. background iAs exposure.

Consideration of a normal prior distribution for the pooled slope parameter instead of the gamma distribution (which constrains estimated slope values to be positive) resulted in an increase in mean lifetime extra risks of 28% at 0.13 μg/kg-day daily iAs intake. Use of the logistic model (i.e., power = 1) vs. the logistic-power model resulted in similar increases in lifetime extra risks.

Finally, the influence of the individual studies on the dose-response meta-analysis result (see Table C-57) were tested. With one exception, the effect of removing single studies from the analysis was minimal, with β_mean values differing by less than 35%. The exception was the cohort study of James et al. (2015) which is not surprising as this study reported the highest IHD elevations at low-dose iAs exposures. In this case, the removal of that study reduced the mean β_mean slope estimates by approximately 61%.

In summary, inclusion of a background inhalation exposure had the least (≤0.3%) and the exclusion of James (61%) would have the greatest impact on the β_mean logistic slope estimates for IHD. The IHD β_mean logistic slope estimates were moderately impacted by variability/uncertainties in the exposure factors (≤20%), alternative gamma prior distributions (≤13%), or using a normal prior for bmean or the logistic model (≤28%).

### 4.3.8 Bayesian Dose-Response Meta-Analysis Dose-Response Results for Diabetes

Bayesian dose-response analyses for diabetes were conducted as previously described (see Sections 4.3.1 to 4.3.4). As discussed in Section 4.3.2, EPA performed dose-response meta-analyses with low, maximum likelihood, and high dose estimates to investigate dose conversion uncertainties. This section presents the results for dose-response meta-analyses using the MLE doses. The dose-response meta-analyses for diabetes included both case-control and cohort studies; the selected studies, converted doses (low, MLE, high), and effective counts used in the diabetes dose-response meta-analyses are presented in Appendix C.1.2 (Diabetes). See U.S. EPA (2025) for access to all dose-response input and output files for diabetes. U.S. EPA (2024b) provides a structured workflow and variable dictionary for the dose-response files.

A summary of the results of the analyses using the MLE doses is presented in Table 4-8. Plots in Appendix C.1.2 (Diabetes; Summary of Diabetes Dose-Response Meta-Analysis Results for MLE Dose Estimates) provide a comparison of the predicted and observed RRs or ORs for all data sets. The visual fits to all the data sets are adequate.

The posterior mean for β_sigma is an estimate of the standard deviation of the study-specific β parameter estimates around the estimated mean, β_mean, and is therefore a measure of study-to-study heterogeneity with respect to that key parameter. The posterior mean for β_sigma is 0.5680, and its 5th percentile is 0.0179 (see Table 4-8). The mean coefficient of variation (CV), β_sigma/β_mean, is about 1.9, indicating moderately large heterogeneity. This level of diversity across study slopes justifies the decision to model the slope parameters hierarchically (i.e., a separate slope is derived for each study as opposed to estimating a single, common slope for all data sets). Appendix C.1.2 (Diabetes) contains details of the modeling results, including posterior distribution plots for pooled and data-set-specific logistic slope parameters and nonhierarchical and hierarchical model plots for individual studies (see Appendix C.1.2; Summary of Diabetes Dose-Response Meta-Analysis Results for MLE Dose Estimates) and sensitivity analyses (see Appendix C.1.2; Diabetes Sensitivity Analyses).

Table 4-8 Summary of diabetes Bayesian analysis output using MLE dose estimates^a^

Parameter | Mean | Standard deviation | 5% | 95%
β_mean | 0.3056 | 0.2802 | 0.0134 | 0.8414
β_sigma | 0.5680 | 0.8085 | 0.0179 | 2.0316
(Grau-Perez et al., 2017) | 0.7736 | 0.9825 | −0.0372 | 2.9589
(James et al., 2013) | 0.4816 | 0.3675 | 0.0366 | 1.1974
(Pan et al., 2013b) | 0.2467 | 0.1013 | 0.0878 | 0.4205
(Coronado-González et al., 2007) | 0.2082 | 0.0753 | 0.0886 | 0.3368
power | 1.1278 | 0.1319 | 1.0068 | 1.3764

a Inference for Stan model: 4 chains, each with iter = 50,000; warmup = 37,500; thin = 1; post-warmup draws per chain = 12,500, total post-warmup draws = 50,000.

#### Extrapolation of Diabetes Risk to Target Population

Because information on diabetes incidence rates across age groups is not available to populate a lifetable, the posterior distribution for the “pooled” (average) value of the logistic slope parameter, β_mean, along with the power parameter, was used with a summary value of 40% for the U.S. lifetime probability of developing type 2 diabetes (Gregg et al., 2014)^57^ as the input to a lifetable calculation of the lifetime probability of diabetes as a function of iAs dose (average μg/kg-day). The methodology is presented by Allen et al. (2020a) and Allen et al. (2020b). The exposure scenario used for these extrapolations posits a continuous, full lifetime exposure to a constant iAs (i.e., daily) dose.

Using the β_mean values derived for the MLE set of dose estimates from the studies selected for the dose-response meta-analyses results in extra lifetime diabetes risks as a function of iAs dose (μg/kg-day), summarized in Table 4-9 and Figure 4-9. Table 4-9 represents the Bayesian hierarchical model estimation of the relationship between μg/kg-day dose and the risk above an estimate of a U.S. risk associated with a zero iAs dose. Table 4-9 presents lifetime extra risk values at various average daily iAs doses ranging from 0 μg/kg-day to 1.0 μg/kg-day, including 0.13 μg/kg-day, which is the total dose associated with roughly 10 μg/L iAs in drinking water exposure (the current iAs MCL), assuming a 0.011 L/kg-day mean U.S. water consumption rate (U.S. EPA (2019), and a 0.02 μg/kg-day U.S. median dietary background intake.

Table 4-9 Pooled dose-response meta-analysis estimates of extra lifetime diabetes incidence risk (per 10,000) at various average daily iAs doses and U.S. equivalent drinking water above median U.S. doses and exposures using MLE dose estimates ^a,b^

Extra lifetime risk estimates (per 10,000)^a^ | Average inorganic arsenic dose (μg/kg-d)^b^
Extra lifetime risk estimates (per 10,000)^a^ | 0 | 0.1 | 0.13^c^ | 0.2 | 0.3 | 0.4 | 0.5 | 0.6 | 0.7 | 0.8 | 0.9 | 1.0
5th % | 0 | 3.37 | 4.65 | 7.84 | 12.77 | 18.11 | 23.82 | 29.47 | 35.34 | 41.28 | 47.58 | 53.73
Mean | 0 | 97.04 | 129.32^d^ | 207.62 | 325.01 | 447.31 | 573.38 | 702.38 | 833.61 | 966.49 | 1100.49 | 1235.15
95th % | 0 | 273.77 | 363.77 | 582.91 | 907.86 | 1247.49 | 1600.01 | 1962.82 | 2321.40 | 2686.37 | 3050.50 | 3422.84

a Extra lifetime risks are presented as mean risk with 5%–95% probabilities based on mean, 5% and 95% estimates of dose-response slopes.

b Doses used in EPA modeling. U.S. daily background dose is estimated at 0.0365 μg/kg-day, 0.02 μg/kg-day from diet, 0.0165 μg/kg-day from water and 0 μg/kg-day from air (see Section 4.3.4).

a Daily intake associated with the current MCL of 10 μg/L drinking water assuming 0.011 L/kg-day water consumption rate and 0.02 μg/kg-day from diet.

d Lifetime extra risks are presented in terms of risk per 10,000 in this table to contextualize the risks in a hypothetical U.S. cohort of 10,000 individuals exposed for a lifetime. A lifetime risk of 129.32 per 10,000 is equivalent to a risk of 0.012932. This illustrative and contextual presentation is not intended to represent a threshold for adversity or recommended risk or action level.

Figure 4-9 U.S. diabetes lifetime extra risk versus μg/kg-day MLE doses for all doses. See Section 4.3.4 for discussion of 0.0365 μg/kg-day U.S. background dose estimate

The polynomial formulas given in Figure 4-9 are provided for convenience in approximating a lifetime extra risk at doses and exposures other than those presented in Table 4-9^58^. The polynomial trendline for the upper-bound lifetime extra risks (risk = 0.0521x^2^ + 0.2927x, where x = dose) only provide an approximation of the upper-bound lifetime extra risks explicitly calculated using the lifetable approach and use of the trendline can result in overestimates of the lifetable risks exceeding 20% at very low doses (e.g., 0.005 μg/kg-day). This polynomial trendline is appropriate for the estimation of risks at doses up to 1.0 μg/kg-day. Table C-49 also provides lifetable-calculated risks at daily intakes above the RfD, from 0.065 to 1.5 μg/kg-day, at increments of 0.005 μg/kg-day (i.e., mean and 95% upper-bound lifetime extra risk values are reported for > 280 daily intake values). Users that need to generate exact mean or upper-bound lifetime extra risk values at daily intakes other than those reported in Table C-49 can use the Bayesian logistic-power modeling results and lifetable R codes (U.S. EPA, 2025). See the structured workflow, outline, and variable dictionary (U.S. EPA, 2024b) for documentation of modeling files.

#### Summary of Dose-Response Meta-Analysis of Diabetes Studies

General limitations and uncertainties associated with the studies used in the diabetes dose-response meta-analyses were discussed in Section 4.3.1. As for the bladder cancer and lung cancer dose-response meta-analyses, the exposure information from studies used in the dose-response meta-analyses were converted to estimates of lifetime daily doses of total iAs in units of average μg iAs per kg body weight (μg/kg-day). Uncertainties in average lifetime daily doses for the exposure groups and in the conversion to μg/kg-day were accounted for, as described in Section 4.3.2, and the reported counts of cases (and controls in the instance of case-control studies) were adjusted to account for the effect of covariates (see Appendix C.1.1 [Treatment of Dose Uncertainty] and Appendix C.1.1 [Adjusting for Covariates] for details).

Following those adjustments, the dose-response meta-analysis approach described in Section 4.3.4 was applied to a set of four data sets. On the basis of visual inspection, the model fit was considered adequate for all but one dataset. The high dose was dropped to obtain adequate fit for the Pan et al. (2013b) dataset because confidence bounds for at least one dose group were outside of the 90% confidence bounds for the dose-response meta-analysis modeling results (see Appendix C.1.2 [Summary of Diabetes Dose-Response Meta-Analysis Results for MLE Dose Estimates]). The choice of a hierarchical structure was supported by the relatively large variation (with mean estimated CV of about 1.9) estimated by the dose-response meta-analysis. The mean of the posterior distribution for β_mean (using the MLE dose estimates) was 0.3056 (90% credible interval,^59^ 0.0134 to 0.8414) per μg/kg-day, with an estimated power parameter of 1.1278 (95% credible interval, 1.0032 to 1.4754).

The full β_mean and power parameter posteriors were used to derive a posterior distribution of U.S.-specific lifetime extra-risk estimates via a lifetable analysis using a summary value for the U.S. lifetime probability of developing diabetes as summarized in Appendix C.1.2 (Diabetes; Extrapolation to Target U.S. Population) section and by Allen et al. (2020a) and Allen et al. (2020b). As shown in Table 4-9, these U.S.-specific lifetime extra risk estimates were derived for various exposure scenarios (assuming daily intake levels of 0–1.0 μg/kg-day, approximately equivalent to U.S. water iAs exposures of 0–89 μg/L). At 0.13 μg/kg-day (daily intake at the current MCL of 10 μg/L), the mean extra lifetime risk was 129.3 per 10,000 (90% credible interval, 4.7 to 363.8 per 10,000).

The above estimates were derived using the MLE doses estimated for study participants. The effect of the uncertainty in those dose values was examined, combining the uncertainty in the means for the exposure-defined groups and in the conversions necessary to obtain a common metric (i.e., average μg/kg-day) (see Appendix C.1.2 [Diabetes Sensitivity Analyses]). The effect was minimal overall: keeping the estimated power parameter value constant at 1.1278, the pooled logistic slope changed from 0.2999^60^ to 0.3586 (using systematically lower dose values consistent with the level of uncertainty) or 0.2516 (using systematically higher dose values consistent with the level of uncertainty). The low-end and high-end dose values resulting from a combination of various factors indicate the results are not overly sensitive to variability/uncertainties in the exposure factors used to estimate the dose levels.

Other sensitivity analyses performed for the diabetes dose-response meta-analysis investigated the potential impact of alternative gamma prior distributions for β _mean, the inclusion of a background inhalation exposure, the use of urine biomarker studies, and omitting individual data sets from the analysis (see Appendix C.1.2 [Diabetes Sensitivity Analysis]). The sensitivity analysis examining the impact of different gamma prior distributions for β_mean did not result in major differences (<10%) in the posterior distributions of the β_mean parameter (see Table C-48). Incorporation of inhalation exposures in the background estimate of total exposure also did not result in dramatically different estimates of extra risk (≤0.2%). Consideration of a larger daily background exposure (0.11 μg/kg-day) also had minimal impact on estimated lifetime extra risks at the drinking water standard, only decreasing lifetime extra risks by 2%, indicating the lifetable methods used in the assessment are relatively insensitive to the estimates of U.S. background iAs exposure.

Excluding the two urine studies influenced the analysis in different directions. Excluding the Grau-Perez et al. (2017) studies decreased the slope by 23% and the exclusion of Coronado-González et al. (2007) increased the slope by 49%. These results indicate that the urinary biomarker studies have a low-to-moderate impact on the overall estimated association between iAs exposure and diabetes in this dose-response meta-analysis.

Consideration of a normal prior distribution for the pooled slope parameter instead of the gamma distribution (which constrains estimated slope values to be positive) resulted in an increase in mean lifetime extra risks of 37% at 0.13 μg/kg-day daily iAs intake. Use of the logistic model (i.e., power = 1) vs. the logistic-power model resulted in similar increases in lifetime extra risks.

Finally, the influence of the individual studies on the dose-response meta-analysis result was evaluated. Across all included studies, the effect of removing single studies from the analysis was minimal. The study that most influenced the analysis (i.e., its removal changed the pooled estimate of the β_mean parameter the most) was the Coronado-González et al. (2007) data set. In that case, the removal of the study increased the mean of the β parameter by 49%.

In summary, inclusion of a background inhalation exposure had the least (≤0.2%) and study selection has the potential to have the greatest (≤50%) impact on the β_mean logistic slope estimates for diabetes. The diabetes β_mean logistic slope estimates were moderately impacted by variability/uncertainties in the exposure factors (≤20%), alternative gamma prior distributions (≤10%), or using a normal prior for bmean or the logistic model (≤35%).

### 4.3.9 Variability and Uncertainty in Bayesian Dose-Response Meta-Analyses

The EPA IRIS Handbook (USEPA, 2022), Benchmark Dose Technical Guidance (U.S. EPA, 2012), EPA’s Review of the Reference Dose and Reference Concentration Processes(U.S. EPA, 2002b), Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005a) all describe factors that commonly affect the level of variability and uncertainty in dose-response analyses, including consistency in the overall database, dose metrics used for dose-response modeling, model uncertainty, statistical uncertainty in the POD, and uncertainties related to study evaluation such as systematic bias, residual bias, and uncontrolled confounding. This section will qualitatively and, to some extent, quantitatively summarize EPA approaches and sensitivity analysis results that address these factors.

#### Database Consistency

Evaluation of database consistency is enhanced by EPA’s use of only medium or high confidence studies in its dose-response meta-analyses (see study evaluation discussion below). The outcomes selected for dose-response were considered to be generally consistent across studies (see Section 3.2, “Evidence Synthesis:). Concern for inconsistency across studies in dose-response is ameliorated by the use of a meta-analysis, which lessens the impact of a single study’s conclusion. EPA’s endpoint-specific “leave-one-out” sensitivity analyses were used to the evaluate the consistency of studies within the meta-analyses. The most influential studies, Wu et al. (2013) for bladder cancer and James et al. (2015) for IHD, reduced the mean β_mean slope estimates by 68% and 61%, respectively, when removed. These studies are retained in their respective meta-analyses, however, because their findings are supported by other studies of the same or similar populations. For instance, similarly strong dose-responses for bladder cancer as Wu et al. (2013) have been observed in recent urine studies of the same Taiwan population (Lin et al., 2018; Huang et al., 2018; Chang et al., 2016),^61^ and Moon et al. (2013) showed a strong dose-response for IHD in a similar U.S. population as James et al. (2015). The fact that these studies used the same exposure metrics and were conducted in similar study populations suggests that the strong dose-responses observed relative to other studies of the meta-analyses are more likely due to study population differences that result in greater sensitivity to the effect of iAs than study design differences.

#### Conversion to a Common Dose Metric

EPA converted study-specific exposure metrics to a common μg/kg-day dose metric to allow multiple studies to be combined into a single meta-analysis, thereby increasing the precision and reducing the uncertainty of the dose-response modeling results. When a study offers multiple dose metrics, the choice of study dose metric can be important. Unless a population is limited in its source of fluids (e.g., populations that rely almost exclusively on a single well water source), it is important to survey individuals as to their consumption habits to approximate their actual iAs dose from the water source of interest. For example, Baris et al. (2016) observed distinct differences in their findings for cumulative arsenic intake and average arsenic concentration and noted that this “underscores the importance of incorporating water intake when estimating an individual’s total arsenic exposure in low to moderately exposed populations such as that in northern New England.” For this reason, EPA prefers cumulative exposure metrics when available and estimates of intake versus drinking water exposure levels.

As described in Appendix C.1.1 (Treatment of Dose Uncertainty), EPA’s dose conversion approach uses a probabilistic approach wherein the exposure factors necessary to convert study-specific dose metrics into the unified μg/kg-day dose metric is applied. These exposure factors (e.g., body weight, water consumption rat) were assumed to vary within a population and so distributional representation of this variability were applied via Monte Carlo methods to derive posterior distributions of the unified dose metric. The use of a common dose metric allows for the inclusion of studies that used differing dose metrics, such as urinary or toenail biomarkers, as the exposure assessment method along with studies that assessed exposure on the basis of drinking water intake. Application of the empirical relationship between urinary total As concentration and drinking water iAs exposure (as established by the El-Masri and Kenyon PBPK model (El-Masri and Kenyon, 2008) to urinary biomarker studies is considered to provide reliable estimates of total arsenic dose and average daily lifetime intake (μg/kg-day) (Allen et al., 2020a; Allen et al., 2020b). Urinary arsenic and toenail concentrations integrate all sources of oral exposure at the individual level, accounting for arsenic from both water and diet, an important recommendation of NRC (2013), and are established biomarkers (NRC, 1999; Hughes, 2006; Marchiset-Ferlay et al., 2012).

#### Derivation of Effective Counts to Address Confounding

Epidemiological studies report adjusted effect measures, adjusted odds ratios (ORs) and Relative Risks (RRs) that retroactively attempt to factor out the effects of potentially confounding variables in order to estimate the effect specifically associated with the exposure of interest, in this case arsenic exposure. As described in Appendix C.1.1, the Bayesian approach that EPA has adopted for the dose-response analysis (Allen et al., 2020b) is based on likelihoods of observing a particular number of cases. A key aspect of the approach is the conversion of reported cases to a count of cases that reflects only the effect of arsenic. To this end, EPA makes use of a studies published adjusted ORs and RRs and associated standard errors (or confidence limits) to derive adjusted counts referred to as “effective count(s).” “Effective counts” are intended to represent the data that would have resulted in the adjusted OR or RR values had confounding not occurred in the study population. While this quantitatively addresses, uncertainty due to confounding, uncertainties related to factors such as systematic bias, residual bias, and uncontrolled confounding must be addressed qualitatively in study-specific risk of bias reviews.

#### PBPK model

As described in Section 3.1 and the iAs Protocol, Appendix E (link provided in Appendix A), several PBPK models have been developed for evaluating inorganic arsenic exposure. The El-Masri-Kenyon model was chosen as the most appropriate because it incorporates more complex metabolic mechanisms with parameters that were independently derived from experimental and literature data (Kenyon, 2021). The El-Masri-Kenyon model was evaluated using two large data sets (~11,000 and 500 subjects in Bangladesh and Nevada, respectively) which provided matched individual chronic arsenic drinking water exposure and urinary excretion. Quantitative relationships between exposure in drinking water and urine levels of inorganic arsenic were developed for well-studied populations (Bangladesh, Taiwan, U.S., males and females) using age- and population-specific conversions in the dose estimates. The El-Masri-Kenyon model was considered to adequately predict measured data for the overall oral exposure to inorganic arsenic (El-Masri et al., 2018b; El-Masri et al., 2018a).

#### Dose-response model uncertainty

As described in detail in Appendix C.1.1, EPA has examined a large collection of alternative models, within the logistic model umbrella. In particular, two sets of models, totaling 39 models in all, were defined in such a way so as to allow for nonmonotonic or threshold-like dose-response shapes. Using bladder cancer, the endpoint with the largest of the dataset of the four meta-analysis endpoints, as a test case, these complex, nonmonotonic models were compared with the simpler logistic model, which does not assume a nonmonotonic shape. While two of the nonmonotonic (fractional polynomial) models resulted in statistically favorable fits to the bladder cancer dataset, they both exhibited biologically unrealistic behavior suggesting that the odds of disease increase to infinity as dose gets close to zero. To avoid this issue without losing the benefits of a more flexible model that can reflect a threshold-like behavior, EPA has developed an approach that addresses the possibility of threshold, or threshold-like, behavior within the logistic model framework. That approach now constitutes the primary analysis approach, i.e., the logistic-power model. This reduces the uncertainty associated in the meta-analysis by extending the range of doses for which the probability of response is essentially the same as the probability of response at 0 μg/kg-day dose. While this model does not allow nonmonotonicity of response, EPA considers it a better approach for exploring and incorporating the possibility of a threshold. One concern with the use of a model with a power term is that it can take on a biologically untenable steep curvature in the low-dose region when attempting to describe dose-response data for which there is little to no difference between the response levels observed at noncontrol doses. This can result in very imprecise BMDs because the data do not constrain the dose-response curve in this lower dose range, where all the change in response is occurring. For this reason, consistent with EPA’s Benchmark Dose Technical Guidance (U.S. EPA, 2012) constraint recommendation and default settings of the EPA benchmark dose software (BMDS), the power parameter of the logistic-power model used in this assessment is constrained to be 1 or greater. It is recognized that this constraint can result in an underestimation of the true risk for some datasets for which for which there is little to no difference between the response levels observed at noncontrol doses. Conversely, it is recognized that, because no upper-bound constraint is placed on the power parameter, an overestimation of risk can result for datasets that reflect a more shallow to increasing, “hockey-stick” shaped dose-response curvature. Since meta-analyses can conceivably contain datasets with both attributes (i.e., concave-down plateauing and threshold-like behavior), the concerns over both under- and overestimation of risks should be mitigated.

#### Statistical Uncertainty in the POD

One measure of statistical uncertainty in the POD is given by the confidence intervals derived from the EPA meta-analyses. The 95th percentile upper bound on the logistic-power model slope estimate serves as the basis for POD estimates used to derive the CSF and RfD estimates for arsenic. A description of the approach for deriving 5th and 95th percentile confidence intervals for EPA meta-analysis dose-response slope estimates are described in Appendix C.1.1. To further assess variability and uncertainty in the POD derivations, EPA conducted comprehensive endpoint-specific sensitivity analyses of factors that can impact the meta-analysis POD derivation. Additional sensitivity analyses performed by EPA for each meta-analysis provide insights into the variability and uncertainty associated with the assumption that the general U.S. population is not appreciably exposed to iAs via inhalation, consideration of a “high-end” estimate for the U.S. background iAs exposure level, considerations of alternative gamma prior distributions for the pooled slope parameter, the use of a prior for the pooled slope that allows negative values, and the calculation of the cancer slope factor with varying numbers of doses. These sensitivity analyses involved comparing the slope derived from the logistic-power model meta-analysis for each endpoint using the mean power parameter estimate derived for that endpoint.

Although inhalation of inorganic arsenic is not considered a primary route of exposure for the general public, the World Health Organization (WHO) estimates that background exposure may range from 0.02 to 0.6 μg/day in areas without substantial arsenic emissions from anthropogenic sources. EPA’s sensitivity analysis using these estimates to incorporate inhalation exposures in the background estimate of total exposure did not result in appreciably different estimates of extra risk for any of the four endpoints assessed by meta-analyses.

This assessment uses an assumed background iAs exposure level of 0.0365 μg/kg-day based on a median background dietary exposure level of 0.02 μg iAs/kg-day (Xue et al., 2010) and 0.0165 μg iAs/kg-day from drinking water (estimated from the median U.S. Country average inorganic arsenic drinking water concentration [1.5 μg/L] from USGS data (Mendez et al., 2017) multiplied by the average water intake rate in the U.S. population of 0.011 L/kg-day [U.S. EPA (2019), Table 3-1, “All Ages”]). However, there is some uncertainty in the determination of this background exposure level and different values for the dietary and drinking water components of the estimate could have been used. For example, the mean dietary exposure level of 0.05 μg iAs/kg-day from Xue et al. (2010) could have been used, as well has a higher estimate of drinking water exposure of 0.06 μg iAs/kg-day, sourced from Mantha et al. (2016). Using this “high-end” estimate of 0.11 μg iAs/kg-day for the background iAs exposure only decreases the mean lifetime extra risk at the drinking water standard of 10 μg/L (corresponding to 0.13 μg/kg-day daily intake) less than 5%, indicating that the lifetable methods used are relatively insensitive to the estimates of U.S. background iAs exposure.

The sensitivity analyses of the gamma prior distribution assumption for the β_mean parameter revealed that different gamma prior distributions for β_mean did not result in large differences in the posterior distributions of the β_mean parameter for any endpoint. They also suggest that the results of the meta-analysis are heavily influenced by the actual data being modeled and are not inappropriately driven by the prior assumptions of the Bayesian modeling.

The last sensitivity analysis considered for each endpoint assessed whether the estimation of the cancer slope factor was influenced by the number of risk-at-a-dose values used to characterize the linear trendline. The conclusion drawn from this sensitivity analysis across all endpoints was that the number of risk-at-a-dose values used to define the cancer slope factor appeared to have almost no effect on the estimated slope factor.

#### Study Evaluation

Study evaluations were performed, and low confidence and uninformative studies were excluded from the EPA meta-analyses of bladder cancer, lung cancer, diabetes and IHD. The potential for uncontrolled confounding was considered during the study evaluation and reflected in the individual domain ratings relevant to that issue. Details on individual domain and overall confidence ratings for each study are available in HAWC. Overall confidence ratings are holistic judgments based on all domains considered, but studies with critical deficiencies in the confounding domain are not generally considered medium or high confidence. In addition, smoking was considered an essential confounder for study selection for dose-response, i.e., studies that did not control for this factor were excluded.

Concerns regarding uncontrolled confounding, systematic error, or other potential residual bias in a particular study are ameliorated in the dose-response meta-analysis through the use of multiple studies rather than reliance on a single study alone and through the use of sensitivity analyses to explore differences in results based on distinct study approaches. First, meta-analysis allows for the integration of results based on studies with differing strengths and weaknesses, thereby lessening the impact of any particular study’s limitations. And second, some sensitivity analyses incorporated into this assessment can be considered a form of triangulation (Lawlor et al., 2016). For example, in sensitivity analyses stratifying by dose metric, results indicated that removal of urinary studies from the lung cancer and diabetes meta-analyses did not change the dose-response slope by more than 20% with the individual studies influencing the results in both directions.

### 4.3.10 Summary of Bayesian Dose-Response Meta-Analysis Results

Sections 4.3.5 and 4.3.6 present the full details for the dose-response modeling of bladder cancer and lung cancer, respectively, including information on dose-response data set selection, modeling approaches, and detailed results. For all ingestion pathway endpoints, lifetime extra risk estimates are presented in relationship to mean U.S. background rates for bladder cancer incidence and lung cancer incidence of 1.9% and 5.7%, respectively. (see Section 4.3.4). These background rates are assumed to be associated with median or “typical” U.S. arsenic lifetime daily background intake of 0.0365 μg/kg-day from dietary, drinking water, and air exposure to inorganic arsenic (see Section 4.3.4). Risk at zero iAs dose is estimated so that extra risk above zero iAs dose can be calculated. Extra lifetime risks and 5th and 95th percentile estimates from the dose-response models are presented in Tables 4-3 and 4-5 for bladder cancer and lung cancer, respectively, for a range of arsenic daily intakes, roughly corresponding to a range of daily arsenic intakes up to 1.0 μg/kg-day. For example, at a daily iAs intake of 0.13 μg/kg-day (the total dose associated with roughly 10 μg/L iAs in drinking water assuming a 0.011 L/kg-day water consumption rate and 0.02 μg/kg-day dietary background intake, the lifetime extra risks for bladder cancer and lung cancer are 7.9 × 10⁻^4^ (90% CI: 8 × 10⁻^6–^2.2 × 10⁻^3^) and 1.0 × 10⁻^3^ (90% CI: 2.5 × 10⁻^5–^2.7 × 10⁻^3^), respectively. For all estimates, including lung cancer from oral exposures, extra risks are calculated assuming zero inhalation exposure.

Polynomial and linear (slope factor) formulas for approximating the predicted means and 5th and 95th percentiles for lifetime extra risk for bladder cancer and lung cancer at any given μg/kg-day dose are presented in the dose-response plots provided in Sections 4.3.5 and 4.3.6.^62,^ ^63^ Although a nonlinear logistic-power model was used in the dose-response meta-analyses, a linear trendline was provided below 0.2 μg iAs/kg-day dose, given that this dose is assumed to cover the majority of drinking water exposure scenarios in the U.S. (see discussion in Section 4.3.5). For this assessment, the cancer slope factor is defined as the slope of the linear trendline between the estimated 95% upper bound on lifetime extra risk and dose. Defined in this way, the approximate cancer-specific slope factors for bladder cancer and lung cancer are 1.76 × 10⁻^2^ (μg/kg-d)⁻^1^ and 2.13 × 10⁻^2^ (μg/kg-d)⁻^1^, respectively. These CSFs can be multiplied by an estimate of a lifetime oral μg/kg-day dose to approximate a 95% upper-bound lifetime extra risk for the endpoint in question. A combined slope factor of 3.17 × 10⁻^2^ (μg/kg-d)⁻^1^, representing the risk of developing either tumor, was derived assuming that individual tumor risks are normally distributed (see Section 4.7).^64^

Sections 4.3.7, 4.3.8, 4.4, and 4.5 present the full details for the dose-response modeling of ischemic heart disease (IHD), diabetes, fetal, newborn, and infant health outcomes, and developmental neurodevelopmental effects, respectively, including dose-response data set selection, modeling approaches, and detailed results for each endpoint/exposure pathway. RfD derivations are fully described in Section 4.6.

For all ingestion pathway endpoints, lifetime extra risk estimates, calculated using the Bayesian dose-response meta-analysis approach, are presented in relationship to mean U.S. background rates for of 40% for IHD and diabetes outcomes (see Sections 4.3.7 and 4.3.8). These background rates are assumed to be associated with median or “typical” U.S. arsenic lifetime daily background intake of 0.0365 μg/kg-day from dietary, drinking water, and air exposure to inorganic arsenic (see Section 4.3.4). Risk at zero iAs dose is estimated so that extra risk above zero iAs dose can be calculated. Extra risks and 5th and 95th percentile estimates from the dose-response models are presented for a range of daily arsenic intakes up to 1.0 μg/kg-day. For all estimates extra risks are calculated assuming zero inhalation exposure. As an example, at a daily iAs intake of 0.13 μg/kg-day, the lifetime extra risks for IHD and diabetes are 1.1 × 10⁻^2^ (90% CI: 3.7 × 10⁻^4–^ 2.9 × 10⁻^2^) and 1.3 × 10⁻^2^ (90% CI: 4.7 × 10⁻^4–^3.6 × 10⁻^2^), respectively. Table 4-10 summarizes the lifetime extra risks estimated at the drinking water standard of 10 μg/L (i.e., 0.13 μg/kg-day) for bladder cancer, lung cancer, IHD, and diabetes.

Table 4-10 Lifetime extra risks at 0.0365 μg/kg-day and 0.13 μg/kg-day for bladder cancer, lung cancer, IHD, and diabetes

Endpoint | Lifetime extra risks (per 10,000) | Trendlines
Endpoint | 0.13 μg/kg-d | Trendlines
Bladder cancer | 7.87; (90% CI: 0.08, 22.4) | Linear, mean: y = 0.0062x; Linear, 95th UB: y = 0.0176x; Polynomial, mean: y = 0.0046x^2^ + 0.0053x; Polynomial, 95th UB: y = 0.0184x^2^ + 0.0137x
Lung cancer | 10.05; (90% CI: 0.25, 27.42) | Linear, mean: y = 0.0078x; Linear, 95th UB: y = 0.0213x; Polynomial, mean: y = 0.0025x^2^ + 0.0077x; Polynomial, 95th UB: y = 0.0074x^2^ + 0.0206x
IHD | 109.96; (90% CI: 3.68, 290.59) | Polynomial, mean: y = 0.0187x^2^ + 0.0878x; Polynomial, 95th UB: y = 0.0459x^2^ + 0.2289x
Diabetes | 129.32; (90% CI: 4.65, 363.77) | Polynomial, mean: y = 0.0205x^2^ + 0.1039x; Polynomial, 95th UB: y = 0.0521x^2^ + 0.2927x

## 4.4 FETAL, NEWBORN, AND INFANT HEALTH OUTCOMES

The basis for study selection for screening analyses of exposure-response for the fetal, newborn, and infant health effects are described by Hobbie et al. (2020), Section 4.2, and Appendix C.2.1. For these effects, the screening-level analyses presented in Section 4.2 indicated Bayesian dose-response meta-analysis approach used for bladder cancer, lung cancer, IHD, and diabetes would not be feasible due to the general lack of dichotomous, relative risk studies for these health outcomes. Additionally, it was unclear how to apply a lifetable approach to estimate risk of birth outcomes, and so a dose-response meta-analysis approach similar to that employed for birth weight in a previous IRIS assessment (U.S. EPA, 2024a) was used. See U.S. EPA (2025) for access to all dose-response input and output files for body weight.

On the basis of literature searches up to August 2022 (see Section 2.1), 80 fetal, newborn, and infant health outcomes high or medium confidence studies were identified and advanced for consideration for dose-response (see Figure 4-10).

Figure 4-10 Study selection flow for identification of studies for fetal, newborn, and infant health outcomes dose-response analyses (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Dose-Response-Inclusion/))

For fetal, newborn, and infant health outcomes, two sub-outcomes reached an evidence synthesis judgment of moderate: 1) fetal & infant mortality; 2) birth weight. In general, dose-response modeling on mortality outcomes is not the preferred option when alternatives (especially those that may be more sensitive) are available. Therefore, birth weight was prioritized as the endpoint carried forward for dose-response analysis.

As noted in Section 4.3.1, the dose-response study selection for fetal, newborn, and infant health outcomes now explicitly considers whether a study controlled for maternal smoking or secondhand smoke, given their roles as potential key confounders in the relationship between arsenic and these outcomes (Salihu and Wilson, 2007). In the conduct of the dose-response study-selection process, a study was considered to have addressed smoking if it was reported that mothers in the study did not smoke or were not exposed to secondhand smoke during pregnancy, if a study reported children were not exposed to smoke during early childhood, or if smoking was considered in statistical models as a confounder. If a study did not mention smoking or how the authors addressed confounding due to tobacco smoke exposure and smoking rates in the population were anticipated to be non-negligible, the study was excluded from consideration for dose-response.^65^

Ultimately, seven cohort studies were considered for dose-response analysis of birth weight outcomes (Rahman et al., 2009; Liu et al., 2018; Liao et al., 2018; Laine et al., 2015; Kile et al., 2016; Goodrich et al., 2019; Gilbert-Diamond et al., 2016). Two data sets were from U.S. populations, two were from Bangladesh, and one each were from China, Taiwan, and Mexico. See interactive HAWC figure (https://hawc.epa.gov/summary/visual/assessment/100500243/Dose-Response-Inclusion/) for full list of which studies were excluded under each selection criterion/consideration. The order of appearance of the criteria/consideration in the HAWC figure above reflects the sequence of application (i.e., confirmation of prioritized endpoint was the first screening criteria). Most studies were excluded because they did not present findings on the prioritized outcome of birth weight or use drinking water or urine as the exposure metric. In other cases, studies were excluded from further analysis because they investigated the effect of iAs on birth weight in a duplicate study population (Rahman et al., 2017b) or reported beta coefficients that were not applicable in the dose-response methods employed by EPA. For example, both Bloom et al. (2015) and Kim et al. (2020) reported beta coefficients for birth weight z-scores, Bloom et al. (2016) reported beta coefficients for tertiles of exposure, not a single beta for the entire population, and Fano-Sizgorich (2021) reported that beta coefficients were estimated with log-transformed urinary tAs concentrations but did not report the base for the log transformation.

Of the studies that reported beta coefficients, only Kile et al. (2016) reported the effect in units of drinking water arsenic (μg/L); all other studies (Rahman et al., 2009; Liu et al., 2018; Liao et al., 2018; Laine et al., 2015; Goodrich et al., 2019; Gilbert-Diamond et al., 2016) reported metrics based on maternal urinary total As concentration (see Table C-63 for study details). For other outcomes in this assessment, use of the El-Masri–Kenyon PBPK model (El-Masri and Kenyon, 2008; El-Masri et al., 2018b; El-Masri et al., 2018a) allows for the conversion of urine biomarker data to oral doses. However, there is uncertainty about application of this model to populations of pregnant women, so it was not used for birth weight. Instead, a study by Gilbert-Diamond et al. (2016) that reports the relationship between maternal urinary total As and drinking water concentrations was used to allow for consideration of studies that report maternal urinary concentrations for fetal, newborn, and infant health outcomes. Similarly, studies reporting iAs levels in toenails were not considered for birth weight as the previously discussed algorithm that allows the conversion of toenail iAs concentrations into drinking water concentrations (Moon et al., 2013; Karagas et al., 2002) was only established in adult populations.

EPA additionally considered how each of these studies accounted for gestational age. Given the potential mediating role of gestational age on the association between arsenic and birth weight (Wilcox et al., 2011; Kile et al., 2016), EPA’s primary meta-analysis to derive a POD for birth weight was restricted to maternal urinary studies that did not adjust for this variable (Rahman et al., 2009; Liu et al., 2018; Laine et al., 2015). A sensitivity analysis consisting of a meta-analysis with all six maternal urinary studies is additionally reported in the assessment (see Appendix C.2.1). Separately, we also present an individual analysis of the Kile et al. (2016) study, which explored mediation by gestational age through structural equation modeling (SEM). Although Kile et al. (2016) was conducted in a Bangladeshi population, it was considered suitable for deriving a candidate value for the general U.S. population based on it being a medium confidence study with a “definitely low risk of bias” and “probably low risk of bias” determinations for the critical domains concerning confidence in how the study accounted for important confounding variables and exposure assessment, respectively. The study also was found to have a “definitely low risk of bias” for the outcome assessment domain. Regarding this study being conducted in a Bangladeshi population, a potential concern would be whether this study represented a “high-exposure” population compared with a general U.S. populations. While this study was conducted in a population that does have a higher upper bound on exposure than the general U.S. population, the concern appears to be somewhat mitigated by the study authors reporting that “… arsenic exposures were relatively modest with a median concentration of 2.3 μg/L in drinking water at the time of enrollment (interquartile range: 0.9, 36 μg/L).”

### 4.4.1 Point of Departure Estimation for Birth Weight Studies

Two of the seven studies that made it through study selection used log-transformed arsenic concentrations as the exposure metric: Kile et al. (2016) used natural log-transformed values (i.e., β coefficient = g per ln(μg/L) iAs in drinking water) and Liu et al. (2018) used log_2_ transformed values (i.e., β coefficient = g per log_2_(μg/L) maternal urinary tAs). In order to use the β coefficients from these studies in a meta-analysis with β coefficients from studies that did not use a log-transformed exposure metrics, the β coefficients for Kile et al. (2016) and Liu et al. (2018) were re-expressed in terms of per μg/L according to Dzierlenga et al. (2020)^66^ For example, Kile et al. (2016) reported a β coefficient of −17.4 g (95% CI: −22.8, −12.0) per ln(μg/L) increase for the association between birth weight and iAs concentrations in drinking water. Given the reported study-specific median (2.3 μg/L) and interquartile range (IQR: 0.9–36 μg/L of exposure, the distribution of exposure was estimated by assuming the exposure follows a log-normal distribution with mean and standard deviation:

μ = l n (q_50_) = l n ( 2.3 ) = 0.83 (4-2)

σ = l n (q_75_ / q_25_) / 1.349 = l n ( 0.9 / 36 ) / 1.349 = 2.73 (4-3)

Then, the 25th through 75th percentiles at 10 percentile intervals of the exposure distribution and corresponding responses of reported β coefficient were estimated. The re-expressed β coefficient is determined by minimizing the sum of squared differences between the curves generated by the re-expressed β and the reported β. Doing so results in a re-expressed β coefficient of −3.91 g (95% CI: −5.13, −2.7) per μg/L. The same approach was used to re-express the β coefficient for Liu et al. (2018).

For continuous data, the typically preferred definition of the benchmark response (BMR) includes a consideration of what constitutes a minimal level of change in the endpoint that is biologically significant. For birth weight, there is no accepted percent change that is considered adverse. However, there is a clinical definition of what constitutes an adverse effect for birth weight: babies born weighing less than 2,500 g (5.5 lbs.) are considered low birth weight (WHO, 2004), and low birth weight is associated with a wide range of health conditions throughout life (Hack et al., 1995; Reyes and Mañalich, 2005; Tian et al., 2019).

The CDC Wonder site (https://wonder.cdc.gov/natality.html) provides vital statistics for babies born in the United States and using this data confers multiple benefits. First, in 2018, 3,791,712 live births occurred in the United States, according to final natality data, with a mean birth weight (± standard deviation) of 3,261.6 ± 590.7 g (7.19 ± 1.30 lbs.). Using a dataset with this many subjects ostensibly confers increased precision in estimating the “background” birth weight to use in BMD calculations compared with study-specific estimates of birth weight. Also, the CDC Wonder database can be queried so that the exact percentage of the population falling below the cut-off value for clinical adversity can be determined. One uncertainty in the use of the Wonder site birth weight data for BMR estimation is its appropriateness when using that BMR in conjunction with a beta reported from a non-U.S. study. However, EPA is not aware of any queryable database of birth weight data for the countries used in the birth weight analyses (i.e., Bangladesh, Taiwan, or Mexico). Given this lack of queryable birth weight data in non-U.S. populations, and the intent to derive a POD that is relevant to U.S. populations, use of the Wonder site birth weight data was deemed appropriate for defining the BMR level.

In the 2018 U.S. natality data, 8.27% of live births fell below the public health definition of low birth weight (i.e., 2,500 g). Given the clinical cut-off for adversity (i.e., birth weight below 2,500 g) and the observation that 8.27% of all live U.S. births were below this cut-off in 2018, the hybrid approach (U.S. EPA, 2012) can be used to define the BMR for this continuous endpoint. The hybrid approach harmonizes the definition of the BMR for continuous data with that for dichotomous data, and therefore is an advantageous approach.^67^ Essentially, the hybrid approach involves estimating the dose that increases the percentile of responses falling below (or above) some cut-off for adversity in the tail of the response distribution. Application of the hybrid approach requires selecting an extra risk value for BMD estimation as well as the cut-off value for adversity. In the case of birth weight, an extra risk of 5% is selected, given this level of response is typically used when modeling developmental responses from animal toxicological studies and has been used in IRIS assessments when modeling epidemiologic data (U.S. EPA, 2024a), and low birthweight confers increased risk for adverse health effects throughout life, thus supporting a BMR lower than the standard BMR of 10% extra risk. A BMR of 1% might also be considered for such an adverse effect occurring during a sensitive lifestage; however, a 1% BMR is typically reserved for the most severe effects, such as outcomes closely associated with mortality or complete loss of function. Thus, a BMR = 5% extra risk was considered most appropriate.

Therefore, given a background response and a BMR = 5% extra risk, the BMD would be the dose that results in 12.86% of the responses falling below the 2,500 g cut-off value:

E x t r a R i s k ( E R ) = ( P ( d ) − P ( 0 ) ) / ( 1 − P ( 0 ) ) (4-4)

P ( d ) = E R ( 1 − P ( 0 ) ) + P ( 0 ) = 0.05 ( 1 − 0.0827 ) + 0.0827 = 0.1286 (4-5)

Using the mean birth weight for all U.S. births of 3,261.6 g (with a standard deviation of 590.7 g), EPA calculated the mean response that would be associated with the 12.86th percentile of the normal distribution falling below 2,500 g. In this case, the mean birth weight would be 3,169.2 g.

The meta-analysis, restricted to the three studies (Rahman et al., 2009; Liu et al., 2018; Laine et al., 2015) that did not control for gestational age, resulted in a pooled β coefficient of −1.28 g per μg/L maternal tAs (95% CI: −2.05, −0.52) (see Appendix C.2.1 for details).^68^ The BMD was calculated by rearranging the equation y = mx + b and solving for x, using 3,261.6 g for the b term and −1.28 for the m term. Doing so results in a value of 72.19 μg/L:

x = ( y − b ) / m = ( 3 , 169.2 g − 3 , 261.6 g ) / (− 1.28 g ( μ g / L )^− 1^) = 72.18 μ g / L (4-6)

To calculate the BMDL, the method is similar, except the lower limit on the β coefficient is used for the m term. The pooled analysis a two-sided 95% confidence interval for the β coefficient (−2.05, −0.52 g per μg/L), meaning that the lower limit of that confidence interval corresponds to a 97.5% one-sided lower limit. The BMDL is defined as the 95% lower limit of the BMD (i.e., corresponds to a two-sided 90% confidence interval), so the proper lower limit on the β coefficient needs to be calculated before calculating the BMDL. The standard error for the pooled β coefficient is 0.39, meaning that the corresponding 95% one-sided lower bound on the β coefficient can be calculated as:

95 % o n e s i d e d L L = β − 1.645 ( S E ( β ) ) = − 1.28 g ((μ g)/(L))^− 1^ − 1.645 (0.39 g ((g)/(L))^− 1^) = − 1.92 g ((μ g)/(L))^− 1^ (4-7)

Using this value for the m term results in a BMDL value of 48 μg/L maternal urinary tAs. Given the BMD and BMDL are in units of μg/L maternal urinary tAS, an approach is needed to convert this dose metric into units of μg/kg-day daily intake. Gilbert-Diamond et al. (2016) investigated the association of drinking water ingestion and rice consumption on maternal urinary tAs concentration; applying equation Eq. 52 (see Appendix C.2.1), and adjusting for body weight, a BMD of 1.59 μg/kg-day and a BMDL of 1.4 μg/kg-day were derived for the three-study meta-analysis.

The same procedure was used to estimate a BMD and BMDL from the β coefficient reported in Kile et al. (2016) (modeled individually as it was the only birth weight drinking water study), re-expressed to the normal scale (beta: −3.91 g per μg/L, 95% CI: −5.13, −2.7). Using this beta and its 95% one-sided confidence interval (calculated as above) results in BMD of 23.6 μg/L and a BMDL of 18.7 μg/L. The BMD and BMDL, in units of μg/L drinking water, was then converted into units of μg/kg-day daily intake by multiplying by 0.01 L/kg-day, the mean U.S. water consumption rate for pregnant women (U.S. EPA, 2019), see Table 3-62, “Community Water”) and adding a 0.02 μg/kg-day median U.S. dietary background dose (Xue et al., 2010). This results in a BMD and BMDL in units of daily intake of 0.256 μg/kg-day and 0.207 μg/kg-day, respectively.

## 4.5 DEVELOPMENTAL NEUROCOGNITIVE EFFECTS

The basis for study selection for screening analyses of exposure-response for the developmental neurocognitive effects are described by Hobbie et al. (2020), Section 4.2, and Appendix C.3.1. For developmental neurocognitive effects, the screening-level analyses indicated the Bayesian dose-response meta-analysis approach described in this assessment would not be feasible due to the lack of dichotomous, relative risk studies for this endpoint. Therefore, a dose-response approach similar to that employed for birth weight was used. See U.S. EPA (2025) for access to all dose-response input and output files for developmental neurocognitive effects.

On the basis of literature searches up to September 2024 (see Section 2.1), 63 developmental neurocognitive high or medium confidence studies were identified and advanced for consideration for dose-response.

Figure 4-11 Study selection flow for identification of studies for developmental neurocognitive dose-response analyses (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Dose-Response-Inclusion/))

For developmental neurocognitive outcomes, one sub-outcome reached an evidence judgment of moderate: cognitive deficits. Therefore, studies of cognitive deficits were carried forward for dose-response modeling while other neurodevelopment outcomes were not advanced (i.e., social, behavioral, and emotional effects; motor effects).

As noted in Section 4.3.1, the dose-response study selection for developmental neurocognitive effects now explicitly considers whether a study controlled for maternal smoking during pregnancy and/or secondhand smoke during childhood, given its role as a potential key confounder in the relationship between arsenic and developmental neurocognitive outcomes (Chen et al., 2013a; Anderko et al., 2010).^69^ In the conduct of the study-selection process, a study was considered to have addressed smoking if it was reported that mothers in the study did not smoke or were not exposed to secondhand smoke during pregnancy, if a study reported children were not exposed to smoke during childhood, or if smoking was considered in statistical models as a confounder. If a study did not mention smoking or how the authors addressed confounding due to tobacco smoke exposure and smoking rates in the population were anticipated to be non-negligible, the study was excluded from consideration for dose-response. In addition to smoking, other important confounders such as sex, age, socioeconomic status (e.g., education or income) were also considered as part of the study evaluation process (see Section 1.6.2 above and additional details in HAWC: https://hawc.epa.gov/assessment/100500243/). The full list of confounders controlled for in the individual studies are listed in Table C-64.

For other outcomes in this assessment, use of the El-Masri and Kenyon PBPK model (El-Masri and Kenyon, 2008; El-Masri et al., 2018b; El-Masri et al., 2018a) allows for the conversion of urine biomarker data to oral doses. However, there is uncertainty about application of this model to populations of pregnant women or children. Instead, a study by Gilbert-Diamond et al. (2016) that reports the relationship between maternal urinary total As and drinking water concentrations was used to allow for consideration of studies that report maternal urinary concentrations for developmental neurocognitive effects. However, EPA is not aware of an approach to reliably convert childhood urinary total As concentrations into drinking water exposures and thus, these studies are excluded from consideration as shown above in Figure 4-11. Similarly, studies reporting iAs levels in toenails were not considered for developmental neurocognitive effects as the Moon et al. (2013) study that allows the conversion of toenail iAs concentrations into drinking water concentrations was established in adult populations.

Ultimately, three cohort studies were considered for the dose-response of developmental neurocognitive outcomes: a study in Spanish children (Soler-Blasco et al., 2022), a study in U.S. children (Signes-Pastor et al., 2022), and a study in Chinese children (Chen et al., 2023). All of these studies reported beta coefficients for IQ tests (full-scale or subscale) based on maternal urinary total As concentration. The IQ tests reported could all be standardized to the same scale., and they all reported an inverse effect. As three studies is generally considered to be sufficient for conducting a meta-analysis, a point of departure for developmental neurocognitive effects was derived based on a meta-analysis of the three selected studies. See interactive HAWC figure (https://hawc.epa.gov/summary/visual/assessment/100500243/Dose-Response-Inclusion/) for full list of which studies were excluded under each selection criterion/consideration. The order of appearance of the criteria/consideration in the HAWC figure above reflects the sequence of application (i.e., confirmation of prioritized endpoint was the first screening criteria). Most studies were excluded because they did not adjust for childhood exposure to smoking, did not present analyses of IQ (full-scale or subscale tests), or did not use drinking water or urine as the exposure metric. Several studies passed all but two of the dose-response screening criteria (i.e., they contained information necessary for dose-response modeling) but were ultimately excluded after further consideration of study characteristics. Four studies investigated the effect of iAs on developmental neurocognitive function based on urinary total As measured in the child’s urine (Rodríguez-Barranco et al., 2016; Jiang et al., 2022; Desai et al., 2018) or blood (Wasserman et al., 2011). There were methodological issues with three additional studies that precluded their further consideration: Rodrigues et al. (2016) reported that beta coefficients for the association between As concentrations and intellectual test z-scores, Vahter et al. (2020) reported beta coefficients for quantiles of exposure rather than a single continuous beta for the entire population (precluding its inclusion in a meta-analysis with other studies), and Patti et al. (2022) based their analysis on DMA and not total As in maternal urine.

### 4.5.1 Point of Departure Estimation for Developmental Neurocognitive

All three of the developmental neurocognitive studies that made it through study selection used log_2_-transformed maternal urinary tAs concentrations as the exposure metric and thus the reported betas are for decreased IQ points per log_2_(μg/L). To derive a POD for developmental neurocognitive effects, a meta-analysis of the three maternal urinary studies was conducted using the study reported beta coefficients to reduce between-study heterogeneity and minimize possible bias from re-expression to the normal scale (i.e., re-expression would only be required for the pooled beta coefficient and not for all three studies used in the meta-analysis). All three studies used different neuropsychological assessments to assess cognitive function at different ages. Soler-Blasco et al. (2022) assessed children at age five using the McCarthy Scale of Children’s Ability (MSCA) and reported children’s general cognitive index (GCI), standardized to a mean of 100 and standard deviation of 15. Chen et al. (2023) assessed children at age two using the Bayley Scales of Infant Development (BSID), which was translated into Chinese and locally standardized. Chen et al. (2023) reported the children’s mental development index (MDI; mean = 100, sd = 15). Lastly, Signes-Pastor et al. (2022) assessed children’s cognitive function at multiple time points using multiple instruments. To align as close as possible to the ages assessed in the Soler-Blasco et al. (2022) and Chen et al. (2023) studies, the results for cognitive tests administered at age two and five in Signes-Pastor et al. (2022) were considered for the meta-analysis. At age two, Signes-Pastor et al. (2022) reported children’s MDI assessed using the BSID; at age five, children’s full-scale IQ (FSIQ) scores were reported as estimated by the Wechsler Preschool and Primary Scale of Intelligence (WPPSI; mean = 100, sd = 15). All three outcomes (BSID-MDI, MSCA-GCI, WPPSI-FSIQ) can be considered IQ outcomes (White et al., 2022) and therefore are appropriate and amenable to the application of a meta-analysis given all three outcomes are standardized to the same scale (i.e., mean = 100, sd = 15). Both Soler-Blasco et al. (2022) and Chen et al. (2023) reported the results for subsets of the neuropsychological assessments used in those studies, such as multiple subtests of the MSCA (verbal, perceptual performance, quantitative, memory, etc.). However, Signes-Pastor et al. (2022) only reported results for the general IQ scores for the three neuropsychological assessments. Thus, IQ scores from the various neuropsychological assessments consistent with full-scale IQ were used in the dose-response assessment.

For continuous data, the typically preferred definition of the benchmark response (BMR) includes a consideration of what constitutes a minimal level of change in the endpoint that is biologically significant. For IQ, different organizations or authoritative bodies have considered similar decrements to be adverse. For example, ATSDR (2022) used a decrease of 1 IQ point to derive a minimal risk level for methylmercury. ATSDR notes that “[w]hile IQ losses ranging from 1 to 5 points are not significant for most children … these small decrements may represent meaningful intellectual and economic achievement at the population level.” Additionally, EPA (2016) (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=4858955) used an IQ loss of 2 points as the basis for setting the 2016 Final Rule for the National Ambient Air Quality Standards for Lead based on comments from EPA’s Clean Air Scientific Advisory Panel that “… a population loss of 1-2 IQ points is highly significant from a public health perspective.”

The hybrid approach was used to define the BMR for developmental neurocognitive effects. For full-scale IQ, adversity can be defined based on the clinical cut-off for mild intellectual disability: IQ below 70 points. The American Psychiatry Association defines mild intellectual disability in school-age children and adults as “… difficulties in learning academic skills involving reading, writing, arithmetic, time, or money, with support needed in one or more areas to meet age-related expectations” (APA, 2013). The clinical definition of mild intellectual disability is a score on a psychometrically valid (White et al., 2022) test of intelligence of approximately two or more standard deviations below the population mean of the test. Given the intellectual tests administered in Signes-Pastor et al. (2022), Soler-Blasco et al. (2022) and Chen et al. (2023) are all standardized to a population mean of 100 and standard deviation of 15, this corresponds to an IQ of 70 representing mild intellectual disability in all of these study populations. Using a standard normal distribution, 2.5% of the population can be expected to fall below this adversity cut-off.

Thus, given the clinical cut-off for adversity (i.e., IQ below 70 points) and the expectation that 2.5% of the population is expected to be below this cut-off, the hybrid approach (U.S. EPA, 2012) was used to define the BMR for this continuous endpoint (see Section 4.4.1 for details on the hybrid definition of the BMR). For developmental neurocognitive effects, an extra risk of 0.5% was selected, meaning the BMD would be the dose that results in 3% of the responses falling below the 70-point cut-off value:

E x t r a R i s k ( E R ) = ( P ( d ) − P ( 0 ) ) / ( 1 − P ( 0 ) ) (4-8)

P ( d ) = E R ( 1 − P ( 0 ) ) + P ( 0 ) = 0.005 ( 1 − 0.025 ) + 0.025 = 0.030 (4-9)

Using the standardized population mean of 100 (standard deviation = 15), EPA calculated the mean response that would be associated with the 3rd percentile of the normal distribution falling below the 70-point cut-off. In this case, the mean IQ score would be 98.24 points, corresponding to a shift in the population mean IQ of approximately 1.75 points. This shift in the population mean IQ is consistent with other dose-response or risk assessment analyses in which shifts of 1 to 2 points are considered adverse (described above).

The meta-analysis for developmental neurocognitive effects resulted in a pooled beta (95% CI) of −1.46 (−3.03, 0.1) IQ points per log_2_(μg/L) increase in maternal urinary tAs concentration. However, in order to calculate the BMD and BMDL in units of μg/L, the pooled beta coefficient (and its confidence interval) must first be re-expressed to the normal scale. To do so, the β coefficient is re-expressed in terms of per μg/mL according to Dzierlenga et al. (2020). First, the distribution of exposure for each individual study was estimated by assuming the exposure followed a log-normal distribution. Then, 100 replicates of random samples (sample size was the same as the reported sample size in each study) were simulated from the exposure distributions for each study included in the meta-analysis, and random samples from all studies were pooled for each replicate to get quantiles from the pooled random samples for each replicate. Lastly, the mean quantiles (median and IQR) from the 100 replicates were used to obtain the exposure distribution for all studies using the equations μ = ln(q50) and σ = ln(q75/q25)/1.349 since the joint distribution of the exposures are also log normally distributed. Doing so results in a re-expressed pooled beta (95% CI) of −0.19 (−0.39, 0.01) IQ points per μg/L increase in maternal urinary tAs concentration.^70^

The BMD, in units of μg/L maternal urinary tAs, was calculated by rearranging the equation y = mx + b and solving for x, using 100 points for the b term and −0.19 for the m term. Doing so results in a value of 9.26 μg/L:

x = ( y − b ) / m = ( 98.24 IQ points − 100 IQ points ) / (− 0.19 g ( μ g / L )^− 1^) = 9.26 μ g / L (4-10)

To calculate the BMDL, the method is similar, except the lower limit on the β coefficient is used for the m term. A two-sided 95% confidence interval for the β coefficient (−0.39, 0.01 IQ points per μg/L) was estimated from the meta-analysis, meaning that the lower limit of that confidence interval corresponds to a 97.5% one-sided lower limit. The BMDL is defined as the 95% lower limit of the BMD (i.e., corresponds to a two-sided 90% confidence interval), so the proper lower limit on the β coefficient needs to be calculated before calculating the BMDL. The standard error of the pooled β coefficient was reported as 0.8, thus the 95% lower confidence limit on the β coefficient is calculated as:

95 % o n e s i d e d L L = β − 1.645 ( S E ( β ) ) = − 0.19 I Q p o i n t s ((μ g)/(L))^− 1^ − 1.645 (0.38 I Q p o i n t s ((μ g)/(L))^− 1^) = − 0.355 g ((μ g)/(L))^− 1^ (4-11)

Using this value for the m term results in a BMDL of 4.96 μg/L. The BMD and BMDL, in units of maternal urinary tAS, were then converted into units of daily iAs intake (in units of μg/kg-day) by first using the Gilbert-Diamond regression equation (as described in Section 4.4.1 and Appendix C.2.1) to convert to units of μg/day, and then dividing by the average body weight for pregnant women (75 kg, U.S. Exposure Factors Handbook, Table 8-29 (U.S. EPA, 2011). This resulted in a BMD of 0.612 μg/kg-day and a BMDL of 0.315 μg/kg-day.

## 4.6 NONCANCER REFERENCE DOSE (RfD) DERIVATIONS

The noncancer reference dose (RfD) values derived in this section are estimates of the total chronic dose to U.S. populations, including sensitive subpopulations or lifestages, likely to be without appreciable adverse health effects. This assessment derives a single overall RfD to cover all health outcomes across all organs/systems. However, organ/system-specific values are also provided as they can be useful for subsequent cumulative risk assessments that consider the combined effect of multiple exposures acting on a common organ/system or mechanism.

### 4.6.1 Study and Endpoint Selection

Data sufficient to support RfD derivation for oral inorganic arsenic exposure were available for all health outcomes identified in Section 4.1. Table 4-11 presents a summary of studies, outcomes, and rationales considered for POD derivation.

Table 4-11 Endpoints considered for derivation of points of departure

Outcome | Reference | Exposure duration | POD derived? | Rationale
IHD | Chen et al. (2013c); Moon et al. (2013); James et al. (2015); Wade et al. (2015).; Wu et al. (2010b) | Chronic | Yes | Evidence judgment conclusion of evidence demonstrates; multiple high confidence studies met study screening criteria for dose-response meta-analysis as described in iAs Protocol (see Section 5.2.2)
Diabetes | Grau-Perez et al. (2017); James et al. (2013); Coronado-González et al. (2007); Pan et al. (2013b) | Chronic | Yes | Evidence judgment conclusion of evidence demonstrates; multiple high confidence studies met study screening criteria for meta-regression dose-response meta-analysis as described in iAs Protocol (see Section 5.2.2)
Birth weight | Kile et al. 2016); Liu et al. (2018); Rahman et al. (2009); Laine et al. (2015) | Gestational | Yes | Evidence judgment conclusion of evidence indicates (likely); multiple high and medium confidence studies showing effects at relevant exposure levels in US-relevant populations
Neurodevelopmental effects | Soler-Blasco et al. 2022); Signes-Pastor et al. (2022); Chen et al. (2023) | Gestational | Yes | Evidence judgment conclusion of evidence indicates (likely); multiple high and medium confidence studies showing effects at relevant exposure levels in US-relevant populations

### 4.6.2 Estimation of Points of Departure for RfD Derivation

The Bayesian dose-response meta-analysis modeling approach used for diabetes and IHD is discussed in Appendix C.1.1. Briefly, after applying the dose-response meta-analysis approach, the benchmark dose (BMD) for diabetes and IHD health is calculated as (see Appendix C.1.3 for full details):

B M D = root((ln ( O R ))/(β), q) = root(((O d d s (P_B M D_) / O d d s (P_0_))/(β), q) (4-12)

Where P_BMD_ and P_0_ are the probabilities associated with 5% and 0% extra risk, respectively, and extra risk is defined as:

E x t r a r i s k = (P_B M D_ − P_0_)/(1 − P_0_) (4-13)

The β and q parameters are the mean pooled logistic slope and power parameters estimated during the Bayesian hierarchical dose-response meta-analysis. BMDs were obtained for diabetes and IHD by solving the equations in Appendix C.1.3 for each ordered sampled pair of β and q from the full posterior distribution and taking the median value. The BMDL for each endpoint was set equal to the 5th percentile of those calculated values.

When calculating a BMD or BMDL, the particular benchmark dose response (BMR) level must be selected a priori in order to perform benchmark dose modeling. Two important considerations in the selection of a BMR level are the severity of the response and whether the resultant BMD would be within the range of the data, preferably near the low end of the observable responses. The effects under consideration, clinically diagnosed type 2 diabetes and IHD, both have a high (40%) lifetime probability of occurrence within the U.S. population (see Section 4.3.4). Diabetes, while a chronic disease, is not considered a frank effect and does not warrant a lower BMR than 5% on the basis of severity. The selection of the BMR for IHD is more complicated given that studies reporting IHD are sometimes incidence studies with no fatal cases of IHD or sometimes include both incident and fatal cases. In the case of the five studies included in the IHD Bayesian dose-response meta-analysis, two studies (Wu et al., 2010b; Wade et al., 2015) were incidence-only studies. EPA does not consider incident cases of IHD as frank effects and thus would select a BMR of 5% extra risks for studies of exclusively incident cases. The remaining three IHD studies (Moon et al., 2013; James et al., 2015; Chen et al., 2013c) included both incident and fatal cases of IHD. The Moon et al. (2013) study provided the incidence numbers for the fatal + incidence and fatal only analyses, the number of incidence cases was calculated and shown to predominate total incidence at low doses (comprising approximately two-thirds of total cases). Overall, the Moon et al. (2013) study reported a roughly 60% incident cases and 40% fatal cases breakdown. Although incidence-only numbers cannot be calculated for the Chen et al. (2013c) or James et al. (2015) studies, it is reasonable to assume this same pattern holds. Therefore, given the mix of incidence-only studies and incidence + fatal studies in the dose-response meta-analysis and BMD derivation, EPA applied a BMR of 5% extra risk for incident cases of IHD and a 1% BMR to fatal cases of IHD, weighted by sample size (see Appendix C.1.3 for full details).

For fetal, newborn, and infant health outcomes, the modeling approach taken was to apply the hybrid benchmark response approach using the pooled beta coefficient for the association of iAs exposure to decreased fetal weight calculated in a three-study meta-analysis (see Section 4.4). A BMR of 5% was selected for this endpoint because the developmental effects were observed during a potentially sensitive lifestage and because a 5% change in markers of growth/development in gestational studies (e.g., fetal weight) has been considered a minimally biologically significant response level.

For developmental neurocognitive effects, the modeling approach taken was to apply the hybrid benchmark response approach using the pooled beta coefficient for the association of iAs exposure to decreased childhood IQ scores calculated in a three-study meta-analysis (see Section 4.5). A BMR of 0.5% was selected for this endpoint given that it corresponds to a decrease in population mean IQ score of approximately 1.75 points and a shift in population IQ of this magnitude has been determined to be relevant to public health (ATSDR, 2022; 2016).

Table 4-12 Points of departure (PODs) considered for use in deriving candidate toxicity values for iAs

Health outcome | Study | Basis for point of departure | Point of departure (μg/kg-d)
Diabetes | Dose-response meta-analysis of four studies | BMDL_05_^a^ | 0.174
IHD | Dose-response meta-analysis of five studies | BMDL_01,05_^a^ | 0.171
Birth weight | Meta-analysis of three studies | BMDL_05_^b^ | 1.4
Birth weight | Kile et al. (2016) | BMDL_05_^c^ | 0.237
IQ score | Meta-analysis of three studies | BMDL_005_^d^ | 0.315

a BMDL calculated as described in Appendix C.1.3.

b A BMDL_05_ of 48 μg iAs/L maternal urinary tAs was first estimated using the hybrid approach as described in Section 4.4 of the assessment, with the BMDL representing the one-sided 95% lower confidence limit on the μg tAs/L exposure that results in an extra risk of 5% of the exposed population having a birth weight below the defined adversity threshold of 2,500 g. This was then converted to 1.4 μg/kg-day total dose using the approach described in Appendix C.2.1.

c A BMDL_05_ of 18.7 μg iAs/L maternal urinary tAs was first estimated using the hybrid approach as described in Section 4.4 of the assessment, with the BMDL representing the one-sided 95% lower confidence limit on the μg tAs/L exposure that results in an extra risk of 5% of the exposed population having a birth weight below the defined adversity threshold of 2,500 g. This was then converted to 0.237 μg/kg-day total dose using the approach described in Appendix C.2.1.

d A BMDL_05_ of 4.96 μg iAs/L maternal urinary tAs was first estimated using the hybrid approach as described in Section 4.5 of the assessment, with the BMDL representing the one-sided 95% lower confidence limit on the μg tAs/L exposure that results in an extra risk of 0.5% of the exposed population having an IQ score below the defined adversity threshold of 70 points. This was then converted to 0.315 μg/kg-day total dose using the approach described in Appendix C.3.1).

### 4.6.3 Derivation of Candidate Toxicity Values

Under EPA’s A Review of the Reference Dose and Reference Concentration Processes (U.S. EPA, 2002b) and Methods for Derivation of Inhalation Reference Concentrations and Application of Inhalation Dosimetry (U.S. EPA, 1994), five areas of uncertainty and variability were considered in deriving the candidate toxicity values for iAs. Table 4-13 presents an explanation of these five areas of uncertainty and variability and the values assigned to each as designated uncertainty factors (UFs) for application to the candidate toxicity values.

Table 4-13 Uncertainty factors for the development of the candidate toxicity values for inorganic Arsenic (iAs)

UF | Value | Justification
UF_A_ | 1 | A UF_A_ of 1 is applied to account for uncertainty in characterizing the toxicokinetic and toxicodynamic differences between experimental animals and humans following oral iAs exposure given that epidemiological studies are exclusively used for the derivation of the RfD.
UF_H_ | 3 | A UF_H_ of 3 is applied to account for potential interindividual differences in pharmacokinetics and pharmacodynamics relating to iAs exposure in humans. A higher UF_H_ is not necessary for IHD, diabetes, fetal, newborn, and infant health outcomes, or developmental neurocognitive PODs resulting from dose-response meta-analyses. These multistudy meta-analyses investigated a heterogeneous mix of multiple study populations, each of which included and adjusted for many sensitive subpopulations and confounders, including smokers, sex, nutritional status, lifestage, genetic variability, and methylation capacity. Results of the extensive leave-one-out sensitivity analyses showed that when studies are iteratively left out of the Bayesian dose-response meta-analyses of IHD or diabetes, the exclusion of a single study does not reduce the estimated pooled logistic slope by more than 63%: excluding the James et al. 2015) IHD study reduces the pooled slope by 61% and excluding the Grau-Perez et al. (2017) diabetes study reduces the pooled slope by 23%. Stated another way, when a single study (possibly reflecting subpopulation sensitivity) is included in the dose-response meta-analysis, the pooled slope never increases by more than ~2.5-fold. This suggests that application of a full 10-fold uncertainty factor to account for interindividual differences is not warranted and a 3-fold UF was applied instead.; A higher UF_H_ was not deemed necessary for the fetal, newborn, and infant POD derived from the Kile et al. (2016) study. The Bangladeshi population that formed the basis of this birth weight POD is known to have a major public health problem with low birth weight, with a notable difference between its 21% background prevalence and the 8.3% U.S. background prevalence (see discussion in Section 4.4). Further, the effect observed in the Kile et al. (2016) study was much stronger than the pooled effect derived by that meta-analysis. EPA considers this to be support that the Kile et al. (2016) study represents a sensitive subpopulation with respective to susceptibility and that a full UF_H_ = 10 is not warranted for this study. Conversely, even though this study population does represent a sensitive subpopulation, it is not likely the most sensitive subpopulation and reducing the UF_H_ to 1 is also not warranted.; Overall, a 3-fold UF is warranted to account for potential interindividual differences in pharmacokinetics and toxicodynamics within the sensitive subpopulations included in the meta-analysis and single study analysis and the fact that a limited set of sensitive populations have been studied and may not represent the total spectrum of sensitive groups. However, when considering population variability, specifically within the context of the entire U.S. population, use of data from these sensitive groups of individuals largely predisposed to developing such effects (as compared with U.S. individuals) does not warrant a higher than 3-fold UF.
UF_S_ | 1 | A UF_S_ of 1 is applied to endpoints observed in the epidemiological studies as most of the studies in the dose-response meta-analysis investigated chronic exposures. Many study populations in the epidemiological studies were assumed to be exposed to iAs for a lifetime and of the studies that explicitly report the duration of exposure, the average was approximately 30 yr. A UF_S_ of 1 is also applied to endpoints observed in gestational epidemiology studies as the developmental period is recognized as a susceptible lifestage where exposure during certain time windows (e.g., pregnancy and gestation) is more relevant to the induction of developmental effects than lifetime exposure.
UF_L_ | 1 | A UF_L_ of 1 is applied for LOAEL-to-NOAEL extrapolation when the POD is determined by modeling or identification of NOAEL.
UF_D_ | 1 | A UF_D_ of 1 is applied given the database of iAs epidemiologic studies is expansive. Identification of studies to include in the dose-response analyses was initially based on a screening-level analysis of 12 endpoints consisting of >200 studies or data sets. From this screening-level analysis, endpoints with the largest databases and percentage of studies with results within 10-fold of the U.S. background iAs exposure (i.e., strongest dose-response relationships) were selected for the Bayesian dose-response meta-analyses. Therefore, an endpoint selection process was used to preferentially advance endpoints with large, complete databases and evidence indicating strong associations of iAs exposure and disease at lower doses. Additionally, the fetal, newborn, and infant health outcome of birth weight and developmental neurocognitive outcome were advanced for additional dose-response analysis and thus, concern over developmental endpoints deriving lower PODs is mitigated as these PODs are considered alongside the PODs derived via dose-response meta-analysis.
UF_C_ | See Table 4-14 | Composite uncertainty factor = UF_A_ × UF_H_ × UF_S_ × UF_L_ × UF_D_.

Table 4-14 lists the candidate toxicity values for iAs as determined after the application of UFs. As described in EPA’s A Review of the Reference Dose and Reference Concentration Processes (U.S. EPA, 2002b), the intraspecies uncertainty factor (UF_H_) is applied to account for “variations in susceptibility within the human population (i.e., interhuman variability) and the possibility (given a lack of relevant data) that the database available is not representative of the dose/exposure-response relationship in the subgroups of the human population that are most sensitive to the health hazards of the chemical being assessed.”

Table 4-14 Candidate toxicity values for inorganic arsenic (iAs)

Endpoint | POD (μg/kg-d) | UF_A_ | UF_H_ | UF_S_ | UF_L_ | UF_D_ | UF_C_ | Candidate toxicity value (μg/kg-d)
Diabetes | 0.174 | 1 | 3 | 1 | 1 | 1 | 3 | 0.058
IHD | 0.171 | 1 | 3 | 1 | 1 | 1 | 3 | 0.057
Birth weight – meta-analysis | 1.4 | 1 | 3 | 1 | 1 | 1 | 3 | 0.47
Birth weight – (Kile et al., 2016) | 0.237 | 1 | 3 | 1 | 1 | 1 | 3 | 0.079
IQ score | 0.315 | 1 | 3 | 1 | 1 | 1 | 3 | 0.105

### 4.6.4 Selection of Lifetime RfD(s)

From among the candidate toxicity values presented in Table 4-14, organ/system-specific RfD (osRfDs) are selected for IHD, diabetes, fetal, newborn, and infant health, and developmental neurocognitive outcomes. Among the two osRfDs for birth weight, the osRfD derived from the Kile et al. (2016) study was selected. Although meta-analyses were preferred, the osRfD derived from the Kile et al. (2016) study was 6-fold lower than the osRfD derived from the three-study meta-analysis. Therefore, the Kile et al. (2016) osRfD was selected in order to ensure health-protectiveness for this endpoint.

The confidence decisions about the study, evidence base, POD quantification, and overall RfD for these organ/system-specific values are fully described in Table 4-15, along with the rationales for selecting those confidence levels. In deciding overall confidence, confidence in the evidence base is prioritized over the other confidence decisions. The overall confidence in the organ/system-specific RfDs for diabetes and IHD is high, and the overall confidence in the organ-specific RfD for fetal, newborn, and infant health outcomes is medium-low.

Table 4-15 Organ/system-specific oral RfDs and confidence for iAs

Confidence categories | Designation | Discussion
Diabetes RfD = 0.058 μg/kg-d
Confidence in studies^a^ used to derive organ/system-specific RfD | High | Confidence in the studies used in the hierarchical Bayesian dose-response meta-analysis of diabetes is high given the analysis is based on the modeling of multiple studies together and these studies were all judged to have study confidence ratings of high or medium.
Confidence in evidence base supporting this hazard | High | Confidence in the evidence base for diabetes effects is high as the hazard conclusion for this endpoint was that “currently available evidence demonstrates that inorganic arsenic causes diabetes in humans under relevant exposure circumstances” (see Section 3.2.2).
Confidence in quantification of the POD_HED_ | High | Confidence in the quantification of the POD and organ-specific RfD is high given the point of departure was based on the hierarchical Bayesian dose-response meta-analysis of multiple high and medium confidence studies within the range of the observed data.
Overall confidence in organ/system-specific RfD | High | The overall confidence in the RfD is high given that the confidence in individual components of the overall confidence determination is also high.
DCS RfD = 0.057 μg/kg-d, based on IHD
Confidence in studies^a^ used to derive organ/system-specific RfD | High | Confidence in the studies used in the hierarchical Bayesian dose-response meta-analysis of IHD is high given the analysis is based on the modeling of multiple studies together and these studies were all judged to have a study confidence rating of high or medium.
Confidence in evidence base supporting this hazard | High | Confidence in the evidence base for IHD effects is high as the hazard conclusion for this endpoint was that “there is robust evidence from a large set of high and medium confidence epidemiologic studies of varied design that demonstrate iAs exposure can cause cardiovascular effects in humans under relevant exposure circumstances” (see Section 3.2.1).
Confidence in quantification of the POD_HED_ | Medium-high | Confidence in the quantification of the POD and organ-specific RfD is medium-high given that there is some uncertainty pertaining to the selection of the benchmark response for this endpoint. However, the point of departure was based on the hierarchical Bayesian dose-response meta-analysis of multiple high and medium confidence studies within the range of the observed data, ultimately supporting the determination of medium-high confidence.
Overall confidence in organ/system-specific RfD | Medium-high | The overall confidence in the RfD is medium-high and is primarily driven by medium-high confidence in the quantification of the POD.
Birth weight RfD = 0.079 μg/kg-d
Confidence in studies^a^ used to derive organ/system-specific RfD | High | Confidence in the study used in the dose-response analysis for birth weight is high based on low risk of bias, a study design that accounted for potential confounders, exposure characterization, and other characteristics that allowed for adequate study sensitivity to detect associations.
Confidence in evidence base supporting this hazard | Medium | Confidence in the evidence base for birth weight (fetal, newborn, and infant health outcomes) is medium as the hazard conclusion for this endpoint was that “the currently available epidemiologic evidence indicates that iAs likely causes fetal, newborn, and infant health outcomes in humans given sufficient exposure conditions” (see Section 3.2.3).
Confidence in quantification of the POD_HED_ | Medium-low | Confidence in the quantification of the POD and organ/system-specific RfD is medium-low. Lack of information on the potential differences in pharmacokinetics and toxicodynamics relating to iAs exposure in U.S. populations, and the uncertainty associated with extrapolating U.S. risk from a study of a single population with a substantially higher sensitivity for this specific outcome, decreases the confidence. That the POD was based on a BMD hybrid approach within the range of the observed data increases confidence.
Overall confidence in organ/system-specific RfD | Medium-low | The overall confidence in the organ/system-specific RfD is medium-low and primarily driven by medium-low confidence in the quantification of the POD.
IQ score RfD = 0.105 μg/kg-d
Confidence in studies^a^ used to derive organ/system-specific RfD | High | Confidence in the studies used in the meta-analysis of birth is high given the analysis is based on the modeling of multiple studies together and these studies were all judged to have a study confidence rating of high or medium.
Confidence in evidence base supporting this hazard | Medium | Confidence in the evidence base for developmental neurocognitive effects (IQ score) is medium as the hazard conclusion for this endpoint was that “the currently available evidence indicates that iAs likely causes neurodevelopmental effects in humans given sufficient exposure conditions” (see Section 3.2.4).
Confidence in quantification of the POD_HED_ | Medium | Confidence in the quantification of the POD and organ/system-specific RfD is medium given that the POD was based on a BMD hybrid approach within the range of the observed data increases confidence and dosimetric adjustment was based on the empirical relationship between drinking water exposure and maternal urinary total As concentrations.
Overall confidence in organ/system-specific RfD | Medium | The overall confidence in the organ/system-specific RfD is medium and primarily driven by medium confidence in the evidence base supporting this hazard and the quantification of the POD.

a All study evaluation details can be found on HAWC.

Table 4-16 summarizes organ/system-specific RfDs for iAs selected in the previous section.

Table 4-16 Organ/system-specific oral RfDs for iAs

System | Basis | POD (μg/kg-d) | UFC | RfD iAs (μg/kg-d) | Confidence
Diabetes | Type 2 diabetes mellitus | 0.174 | 3 | 0.058 | High
Cardiovascular | IHD | 0.171 | 3 | 0.057 | Medium-high
Fetal, newborn, and infant health outcomes | Birth weight | 0.237 | 3 | 0.079 | Medium-low
Developmental neurocognitive | IQ score | 0.315 | 3 | 0.105 | Medium

From the identified human health effects of iAs and the derived organ/system-specific RfDs for cardiovascular effects, diabetes, fetal, newborn, and infant health outcomes, and developmental neurocognitive effects (see Table 4-16), an RfD of 0.06 μg/kg-day, based on increased incidence of diabetes and IHD in humans, was selected as the overall RfD.^71^ The 0.06 μg/kg-day RfD represents an estimate (with uncertainty spanning perhaps an order of magnitude) of a daily oral exposure (above zero dose) for a chronic duration (up to a lifetime) to the human population (including sensitive subgroups) that is likely to be without an appreciable increased risk of diabetes or IHD (over the estimated risk at zero dose) during a lifetime. As described in Table 4-15 confidence in the osRfDs is high for diabetes and medium-high for IHD (acknowledging the uncertainty in selecting the BMR for this endpoint). Accordingly, the overall confidence in the final RfD is medium-high. While the IHD organ/system-specific RfD is based on the lowest POD_HED_ using a dose-response meta-analysis approach that included high and medium confidence studies (0.171 μg/kg-day, compared with 0.174 μg/kg-day for diabetes), rounding the resulting organ-specific RfDs to one significant digit results in identical values (i.e., 0.06 μg/kg-day). The final RfD is expected to be protective against all noncancer adverse health effects associated with iAs and across all life stages. The decision to base the final RfD on both IHD and diabetes was based on all available organ-specific RfDs in addition to overall confidence and composite uncertainty for those RfDs.

### 4.6.5 Previous IRIS Assessment: Reference Value

The previous non-cancer IRIS assessment for inorganic arsenic was posted to the IRIS database in 1991. An oral reference dose (RfD) of 3 × 10^-4^ mg/kg-day (0.3 μg/kg-day) was developed based on a NOAEL for increased hyperpigmentation, keratosis, and possible vascular complications in a human population in an endemic area of chronic arsenic exposure in Taiwan (Tseng et al., 1968; Tseng, 1977). A UF_C_ of 3 was applied to the NOAEL identified in these studies to account for both lack of data to preclude reproductive toxicity as a critical effect and to account for some uncertainty in whether the NOAEL accounts for all sensitive individuals. This RfD was interpreted with medium confidence, based on medium confidence in the principal studies and medium confidence in the database.

## 4.7 CANCER TOXICITY VALUES

As stated in Sections 4.3.5 (bladder cancer) and 4.3.6 (lung cancer), cancer slope factors were derived as the slope of the linear trendline for the upper confidence limit (i.e., 95% upper bound on risk; UCL) on the extra risk associated with doses above background. Although EPA’s modeling approach in this assessment does not assume linearity in response, linear trendline slopes for bladder cancer (1.76 × 10⁻^2^ per μg/kg-day) and lung cancer (2.13 × 10⁻^2^ per μg/kg-day) were provided as the endpoint-specific CSFs below 0.2 μg/kg-day. This dose level (0.2 μg/kg-day ) was selected as the upper dose limit to calculate the CSF because Mendez et al. (2017) reports that the 95th percent upper bound on drinking water concentrations in the United States is 15.4 μg/L, translating to approximately 0.19 μg/kg-day iAs daily intake using a 0.011 L/kg-day water consumption rate and accounting for 0.02 μg/kg-day daily iAs exposure via the diet. Therefore, the provided linear CSFs below this daily dose covers the majority of drinking water exposure scenarios in the United States. The CSFs only provide approximations of the upper-bound lifetime extra risks explicitly calculated using the lifetable approach and using the CSF can result in overestimates of the lifetable risks approximately 20% (bladder cancer) or 15% (lung cancer) at very low doses (i.e., 0.005–0.01 μg/kg-day). Given the nonlinearity in upper-bound lifetime extra risks, linear trendlines beyond 0.2 μg/kg-day are associated with increasingly imprecise estimates, and EPA recommends that the polynomial trendlines provided for bladder cancer and lung cancer be used for daily intakes of up to 1.0 μg/kg-day (see Sections 4.3.5 and 4.3.6). Tables C-31 (bladder cancer) and C-41 (lung cancer) also provide lifetable-calculated risks at daily intakes of 0 μg/kg-day to 1.5 μg/kg-day, at increments of 0.005 μg/kg-day (i.e., mean and 95% upper-bound lifetime extra risk values are reported for 300 daily intake values). Users that need to generate exact mean or upper-bound lifetime extra risk values at daily intakes other than those reported in Tables C-31 or C-41 can use the Bayesian logistic-power modeling results and lifetable R codes (U.S. EPA, 2025). See the structured workflow, outline, and variable dictionary (U.S. EPA, 2024b) for documentation of modeling files.

A combined cancer slope factor, representing the risk of developing either bladder cancer or lung cancer, or bladder and lung cancer, was derived using the method outlined below and described in the Toxicological Review of Chloroprene (U.S. EPA, 2010). Assuming the cancer slope factors are normally distributed, the combined cancer slope factor is calculated as:

C o m b i n e d C S F = ∑ M L E s l o p e f a c t o r s + 1.645 ∗ c o m p o s i t e S D (4-14)

The MLE slope factors are the slopes of the linear trendlines fit to the mean lifetime extra risks in Figures 4-6 (bladder cancer) and 4-7 (lung cancer). The composite SD is calculated as:

sqrt(∑ v a r i a n c e s) = sqrt(∑ ((u p p e r b o u n d − M L E)/(1.645))^2^) (4-15)

Therefore, the combined cancer slope factor is calculated as:

C o m b i n e d C S F = ( 0.0062 + 0.0078 ) + (sqrt(((0.0176 − 0.0062)/(1.645))^2^ + ((0.0213 − 0.0078)/(1.645))^2^) × 1.645) = 3.17 × 10^− 2^ ((μ g)/(k g) − d a y)^− 1^

A combined cancer polynomial trendline was derived using the methods below in order to estimate combined cancer risks above 0.2 μg/kg-day. This approach should be used for exposures greater than 0.2 μg/kg-day because that is the maximum dose for which the linear iAs cancer slope factor (CSF) is considered reliable. To estimate combined cancer risks below 0.2 μg/kg-day, the linear CSF should be used.

First, the estimated probabilities of developing either bladder cancer or lung cancer at zero exposure was determined using the lifetable for each tumor. These probabilities were P_bladder_(0) = 0.01897 and P_lung_(0) = 0.0571.

The probability of developing one or both of the tumors at zero exposure is given as:

P_b l a d d e r , l u n g_ ( 0 ) = 1 − [(1 − P_b l a d d e r_ ( 0 )) ∗ (1 − P_l u n g_ ( 0 ))] (4-16)

Then, ER_bladder_(d) and ER_lung_(d) (where d equals the dose for which the risk calculation is made) were set as the polynomial trendlines for the 95^th^ upper bound on risk for the individual tumor types as reported in Table 4-10:

E R_b l a d d e r_ ( d ) = 0.0184 x^2^ + 0.0137 x

and

E R_l u n g_ ( d ) = 0.0074 x^2^ + 0.0206 x

The probability of each of the tumor types is then given by:

P_b l a d d e r_ ( d ) = [(0.0184 x^2^ + 0.0137 x) ∗ (1 − P_b l a d d e r_ ( 0 ))] + P_b l a d d e r_ ( 0 ) (4-17)

and

P_l u n g_ ( d ) = [(0.0074 x^2^ + 0.0206 x) ∗ (1 − P_l u n g_ ( 0 ))] + P_b l a d d e r_ ( 0 ) (4-18)

The probability of developing one or both of the tumors is given by:

P_b l a d d e r , l u n g_ ( d ) = 1 − [(1 − P_b l a d d e r_ ( d )) ∗ (1 − P_l u n g_ ( d ))] (4-19)

Then, the lifetime extra risk of developing one or both tumors is given by:

E R_b l a d d e r , l u n g_ ( d ) = (P_b l a d d e r , l u n g_ ( d ) − P_b l a d d e r , l u n g_ ( 0 ))/(1 − P_b l a d d e r , l u n g_ ( 0 )) (4-20)

Calculating the lifetime extra risk of developing one or both tumors across a range of doses results in a polynomial trendline approximately given by combined risk = 0.0243x^2^ + 0.035x − 0.0001, see Figure 4-12 below. Note that this trendline is only valid for estimating combined cancer risks above 0.2 μg/kg-day. To estimate combined cancer risks below 0.2 μg/kg-day, the linear CSF should be used instead.

Figure 4-12 Combined cancer lifetime extra risks versus μg/kg-day iAs doses for doses up to 1.0 μg/kg-day

Thus, the lifetime extra risk of developing one or both tumors for a given dose can be approximated for any dose of interest using the equation of the trendline. For example, the lifetime extra risk of developing one or both tumors at a daily intake of 0.25 μg/kg-day would be:

E R_b l a d d e r , l u n g_ ( 0.25 ) = (0.0243 ∗ ( 0.25 )^2^) + ( 0.035 ∗ 0.025 ) − 0.0001 = 0.0102

Conversely, for a given lifetime risk of developing one or both tumors, the quadratic formula can be used to solve for the daily intake value. For example, for a lifetime extra risk of 0.015, application of the quadratic formula returns two roots: 0.35 μg/kg-day and −1.78 μg/kg-day. Because a negative daily dose is not possible, the daily intake of iAs associated with a lifetime extra risk of development one or both tumors would be 0.35 μg/kg-day. This can be visually confirmed by examining Figure 4-12.

### 4.7.1 Previous IRIS Assessment: Cancer Slope Factor

The previous cancer IRIS assessment for inorganic arsenic was posted to the IRIS database in 1995. EPA’s 1995 IRIS assessment classified inorganic arsenic as “Group A – human carcinogen” under the 1986 guidelines (U.S. EPA, 1986). This was based on sufficient evidence from human data for increased lung cancer mortality in multiple populations exposed via inhalation and increased mortality from multiple internal organ cancers (liver, kidney, lung, and bladder) and increased skin cancer in populations consuming drinking water contaminated with arsenic. A cancer slope factor of 1.5 per mg/kg-day was developed based on skin cancer observed in the same Taiwanese population the RfD was based on (Tseng et al., 1968; Tseng, 1977). The multistage model, with time as a variable, was used to predict dose-specific and age-specific skin cancer prevalence rates associated with ingestion of inorganic arsenic.

25 Using the one-sided 95^th^ percent upper bound on risk to derive cancer slope factors is standard practice and is consistent with EPA Cancer Guidelines (U.S. EPA, 2005a).

26 Note that the empirical relationship between urinary total arsenic (tAs) biomarker concentrations and drinking water concentration was established by the El-Masri and Kenyon PBPK model (El-Masri and Kenyon, 2008) and used in all dose conversions of urinary biomarker studies (see Appendix C.1.1 for details and Table C-2 for equations used in conversions. The PBPK model was not run individually for each study.

27 Studies of ischemic heart disease can include only incident cases, only fatal cases, or can include a mix of both incident and fatal cases. The dose-response analysis of ischemic heart disease advanced for candidate toxicity value included incident-only or incident and fatal cases (see Section 4.3.1). However, given the increased severity of fatal vs. nonfatal events, the dose-response analysis for IHD took this into account when defining the benchmark response (see Section 4.6.1 and Appendix C.1.3), and additional sensitivity analyses and comparisons included in Appendix C.1.2 (Ischemic Heart Disease (IHD) Incidence, Fatal IHD Lifetime Extra Risks).

28 Endpoints with Robust strength of evidence: lung cancer, bladder cancer, skin cancer, IHD and CVD, skin lesions, diabetes, stroke; endpoints with Moderate evidence: renal cancer, nonmalignant respiratory disease, pregnancy outcomes (infant morbidity and mortality), neurodevelopmental toxicity, immune effects, liver cancer; See Table 5-3 of Protocol for details.

29 RRB-US estimates are estimated by dividing a study-specific estimate of the exposure level associated with a given relative risk (RRE) by an estimated U.S. background exposure level (in terms of the study-specific exposure metrics); the lower an RRB-US value, the greater the concern. The RRB-US estimates are the focus here as they are more relevant for low exposure populations like the U.S.

30 RRB-US values were not derived if the RRE-US_20_ estimate was more than a factor of three below the central estimate for the lowest dose group or above the central estimate for the highest dose group of the study (Hobbie et al., 2020).

31 The Chile population studied is unique in that, due to limited water sources, almost everyone drinks water from one of the few large public water supplies. Also, 40 years of historical records of iAs concentrations are available for each of these large supplies. So, unlike SW Taiwan, where high exposures came from thousands of small domestic wells with highly variable arsenic concentrations and few historic records, a person’s lifetime arsenic exposure in this area of Chile could be estimated with good accuracy simply by knowing the cities or towns in which that person lived.

32 According to the El-Masri-Kenyon PBPK model, iAs is eliminated almost exclusively in urine. Thus, total μg/kg-day arsenic in urine is a good approximation of μg iAs/kg-day intake, assuming arsenic intake is substantially in the form of iAs. To obtain estimates of μg iAs/kg-day intake, EPA multiplies μg total As/g creatinine (units reported in most studies) by an estimate of g creatinine/kg-day. Urinary creatinine/kg-day is estimated as = (266.16 −47.17 × sex − 2.33 × BMI + 0.66 × age + 0.17 × age^2^) × 113.12/10^6^, where sex is 0 for male and 1 for female and BMI is estimated as BW/(height/100)^2^. EPA employed a Monte Carlo approach for these derivations to assess the impact of exposure factor variability on the μg iAs/kg-day intake estimates (Allen et al., 2020a).

33 According to the El-Masri-Kenyon PBPK model, iAs is eliminated almost exclusively in urine. Thus, total μg/kg-day arsenic in urine is a good approximation of μg iAs/kg-day intake, assuming arsenic intake is substantially in the form of iAs. To obtain estimates of μg iAs/kg-day intake, EPA multiplies μg total As/g creatinine (units reported in most studies) by an estimate of g creatinine/kg-day. Urinary creatinine/kg-day is estimated as = (266.16 −47.17 × sex − 2.33 × BMI + 0.66 × age + 0.17 × age^2^) × 113.12/10^6^, where sex is 0 for male and 1 for female and BMI is estimated as BW/(height/100)^2^. EPA employed a Monte Carlo approach for these derivations to assess the impact of exposure factor variability on the μg iAs/kg-day intake estimates (Allen et al., 2020a).

34 This terminology is consistent with the latest International Classification of Disease-10 (https://icd.who.int/browse10/2016/en#/).

35 Another term used in epidemiological studies, coronary heart disease (CHD), is largely synonymous with IHD, but has no specific ICD code; studies that use the term CHD to define cases are included in the IHD sections of this assessment.

36 The cohort study follow-up durations ranged from ~6 to 40 years. The low end of this range is not deemed a major concern given the short latency period for iAs-induced DCS relative to iAs-induced cancer (Yuan et al., 2007).

37 According to the El-Masri-Kenyon PBPK model, iAs is eliminated almost exclusively in urine. Thus, total μg/kg-day arsenic in urine is a good approximation of μg iAs/kg-day intake, assuming arsenic intake is substantially in the form of iAs. To obtain estimates of μg iAs/kg-day intake, EPA multiplies μg total As/g creatinine (units reported in most studies) by an estimate of g creatinine/kg-day. Urinary creatinine/kg-day is estimated as = (266.16 −47.17 × sex − 2.33 × BMI + 0.66 × age + 0.17 × age^2^) × 113.12/10^6^, where sex is 0 for male and 1 for female and BMI is estimated as BW/(height/100)^2^. EPA employed a Monte Carlo approach for these derivations to assess the impact of exposure factor variability on the μg iAs/kg-day intake estimates (Allen et al., 2020a).

38 As described in Allen et al. (2020a) low and high estimates were obtained by minimizing and maximizing the high-exposure group means, respectively, subject to the constraint that −2*(LL – MLL) < 2.706 (a 95% bound on the high-group mean). LL is the log-likelihood for the log-normal distribution for the candidate parameter vector; MLL is the maximum log-likelihood. When a published study reports the mean or median values for each group, those values are used directly as the group-specific dose values, with no log-normal fitting.

39 1 μg/kg – day is 27 times greater than the estimated U.S. background (median) iAs dose of 0.0365 μg/kg – day.

40 For computational purposes, 85 years was used to define the upper limit for lifetime risk calculations.

41 The lifetable methodology described in Allen et al. (2020b) used the logistic model but is still relevant to the assessment’s use of the logistic-power model. Essentially, when using the logistic-power model, the lifetable methodology uses the iteration-specific values for the logistic slope and power parameters in the calculation of lifetime extra risk, instead of just the logistic slope when using the logistic model.

42 Lloyd-Jones et al. (1999) reported lifetime risks of IHD (CHD) at an index age of 40 years for men (48.6%) and women (31.7%) enrolled in the Framingham Heart Study.

43 Gregg et al. (2014) reported life risks of diabetes from age 20 for men (40.2%) and women (39.6%) in a large (N = 598, 216) study of National Health Interview Survey participants.

44 Median U.S. dietary consumption (Xue et al., 2010) plus median U.S. County average inorganic arsenic drinking water concentration (1.5 μg/L) from USGS data (Mendez et al., 2017) multiplied by the average water intake in the U.S. population of 0.011 L/kg-day (U.S. EPA, 2019) Table 3-1, “All Ages”).

45 The fit of all linear and polynomial bladder cancer trendlines were statistically significant with p-values < 0.0001, as determined by regression analysis in R with the function lm().

46 Traditional cancer slope factors are calculated as CSF = BMR/BMDL, where BMR is the benchmark response and BMDL is the 95% one-sided lower confidence limit on the benchmark dose.

47 Model fit to a study’s dose-response data was considered to be adequate if the confidence interval for each exposure group response estimate overlapped with the confidence interval for the modeled dose-response curve.

48 A credible interval is the Bayesian analog to a confidence interval in frequentist statistics.

49 This bmean value was obtained via Bayesian dose-response analysis with different MCMC settings to minimize computational burden and analysis time (i.e., 25,000 MCMC iterations vs. 50,000). Thus, the bmean reported here is slightly different (0.3642 vs. 0.3694) than the bmean reported in Table 4-2.

50 The fit of all linear and polynomial lung cancer trendlines were statistically significant with p-values < 0.0001, as determined by regression analysis in R with the function lm().

51 Traditional cancer slope factors are calculated as CSF = BMR/BMDL, where BMR is the benchmark response and BMDL is the 95% one-sided lower confidence limit on the benchmark dose.

52 This bmean value was obtained via Bayesian dose-response analysis with different MCMC settings to minimize computational burden and analysis time (i.e., 25,000 MCMC iterations vs. 50,000). Thus, the bmean reported here is slightly different (0.1522 vs. 0.1543) than the bmean reported in Table 4-4.

53 Lloyd-Jones et al. (1999) reported lifetime risks of IHD (CHD) at an index age of 40 years for men (48.6%) and women (31.7%) enrolled in large Framingham Heart Study.

54 The fit of all polynomial IHD trendlines were statistically significant with p-values < 0.0001, as determined by regression analysis in R with the function lm().

55 A credible interval is the Bayesian analog to a confidence interval in frequentist statistics.

56 This bmean value was obtained via Bayesian dose-response analysis with different MCMC settings to minimize computational burden and analysis time (i.e., 25,000 MCMC iterations vs. 50,000). Thus, the bmean reported here is slightly different (0.2545 vs. 0.2602) than the bmean reported in Table 4-6.

57 For diabetes, age-stratified morbidity and mortality values were not available; therefore, a summary estimate of the lifetime probability of developing type 2 diabetes was used instead. Gregg et al. (2014) reported life risks of diabetes from age 20 for men (40.2%) and women (39.6%) in a large (N = 598, 216) study of National Health Interview Survey participants.

58 The fit of all polynomial diabetes trendlines were statistically significant with p-values < 0.0001, as determined by regression analysis in R with the function lm().

59 A credible interval is the Bayesian analog to a confidence interval in frequentist statistics.

60 This bmean value was obtained via Bayesian dose-response analysis with different MCMC settings to minimize computational burden and analysis time (i.e., 25,000 MCMC iterations vs. 50,000). Thus, the bmean reported here is slightly different (0.2999 vs. 0.3056) than the bmean reported in Table 4-8.

61 These studies were not included in the bladder cancer meta-analysis because they were studies of the same population as Wu et al. (2013).

62 To derive the most accurate values, meta-regression models and lifetables should be applied in accordance with methods described by Allen et al. (2020a) and Allen et al. (2020b).

63 These extra risk estimates assume a constant level of daily lifetime intake. That vulnerable windows of exposure may exist is recognized, as suggested by evidence for magnified cancer, cardiovascular, and neurodevelopmental risks following in utero or early-life arsenic exposure (Yuan et al., 2007; Steinmaus et al., 2013; Farzan et al., 2013a).

64 Calculated as described in the Toxicological Review of Chloroprene (U.S. EPA, 2010), assuming a normal distribution and using MLE and 95% upper-bound linear slope estimates shown in Figure 4-6 (bladder cancer) and Figure 4-7 (lung cancer). The combined CSF is calculated as ∑(MLE Slopes) + 1.645 × composite SD. The composite SD is equals sqrt(∑ v a r i a n c e s) = sqrt(∑ ((u p p e r b o u n d − M L E)/(1.645))^2^) = sqrt(((0.0176 − 0.0062)/(1.645))^2^ + ((0.0213 − 0.0078)/(1.645))^2^) = 0.0107 . Thus, the combined CSF equals (0.0062 + 0.0078) + (1.645 ∗ 0.0107) = 0.0317.

65 In addition to smoking, other important confounders such as race/ethnicity, maternal age, maternal alcohol use, measure of SES (e.g., education/income), infant sex, parity, and maternal BMI were also considered as part of the study evaluation process (see Section 1.6.2 and HAWC for more details).

66 A recent study examined the uncertainty introduced by the Dzierlenga re-expression method and reported a bias in the direction of a larger effect estimate, i.e., an overestimation of the true effect estimate, when re-expressing from the log scale to the unlogged scale (Linakis et al., 2024). However, EPA noted that in the analyses of real study data, the authors treated the estimated effect estimates, which are random variables, as if they were constants in their Table 4. Comparing point estimates of random variables ignores their variance, and ignoring variance may lead to unsupported conclusions. EPA noted that had the confidence intervals around the point estimates been compared, the observed regression coefficient would fall within the confidence intervals for the re-expressed regression coefficient when study sample sizes were approximately less than n = 3000. The total sample size for the meta-analysis was 2007 individuals, well within the range of study sizes where reported betas and re-expressed betas are statistically consistent. Thus, EPA judged the Dzierlenga methodology for re-expression to be appropriate.

67 While the explicit application of the hybrid approach has not been commonly used in IRIS dose/concentration/exposure-response analyses, the more commonly used SD-definition of the BMR for continuous data is simply one specific application of the hybrid approach. The SD-definition of the BMR assumes that the cut-off for adversity is the 1.4th percentile of a normally distributed response and that shifting the mean of that distribution by one standard deviation approximates an extra risk of 10%.

68 A sensitivity analysis in which studies that controlled for gestational age in their statistical analyses resulted in a slightly attenuated pooled effect compared to the main analysis: −1.02 g per μg/L (95% CI: −1.71, −0.34). See Appendix C.2 for details.

69 Previously, in the external review draft smoking was not a critical criterion considered, and studies that did not control for or address smoking were considered for dose-response Specifically, dose-response for neurocognitive effects was based on the Wasserman et al. (2014) study. This study did not report if mothers smoked during pregnancy or if children lived in a home where smoking occurred. Therefore, while previously considered for dose-response, this study is now excluded based on this criterion.

70 A sensitivity analysis in which study-specific log_2_-tranformed betas were re-expressed to the normal scale prior to the meta-analysis (instead of performing the meta-analysis on the log_2_-transformed betas and re-expressing post-hoc) resulted in almost identical results to the main analysis: a pooled beta of −0.2 IQ points per μg/L (95% CI: −0.38, −0.02). See Appendix C.3.1 for details.

71 As a reminder, the estimated background dose of 0.0365 μg/kg-day is assumed to be associated with the estimated background risk of IHD.