# 3 PHARMACOKINETICS AND EVIDENCE SYNTHESIS

## 3.1 PHARMACOKINETICS

The behavior of arsenic in the body is complex. After absorption, inorganic arsenic undergoes a complicated series of enzymatic and nonenzymatic oxidation, reduction, and conjugation reactions. Although all these reactions can occur throughout the body, the rate at which they occur varies greatly from organ to organ. In addition, there are important differences in arsenic metabolism across animal species (Drobná et al., 2010), and these variations make it difficult to identify suitable animal models for predicting human metabolic patterns.

Each metabolic transformation affects the subsequent biokinetic behavior (transport, persistence, elimination) and pharmacokinetics of the arsenic species. Thus, absorption, transport, and metabolic processes are highly interdependent and cannot easily be discussed separately. The general pattern involves the gastrointestinal (GI) absorption of inorganic arsenic species, followed by a cascade of oxidation-reduction reactions and methylation steps, resulting in the partial transformation of the inorganic species into mono- or dimethylated species (collectively referred to as MMA and DMA, recognizing that there is often ambiguity in characterizing the oxidation state of the methylarsenic compounds). Conjugated arsenic species, either methylated or not (e.g., glutathione conjugates or other sulfur-containing derivatives), also may be produced.

Several metabolic schemes have been proposed that describe the general pathway that converts inorganic arsenic to its primary metabolites MMA and DMA, regardless of exposure route. These pathways involve numerous enzymes and cofactors. Some of the proposed metabolic pathways involve the cycling of arsenic species back and forth between the +3 (trivalent) and +5 (pentavalent) oxidation states, and there is evidence that key metabolic processes may be saturable, so that metabolic patterns differ with exposure levels. MMA, DMA, and inorganic arsenic levels in tissues, blood, and urine are the most frequently measured metabolites; the relative levels of these compounds in blood or urine are often the primary evidence in support of one or another metabolic pathway. Genomic tools are being increasingly employed to better characterize human arsenic metabolism and to identify individuals at higher risk from arsenic exposures (Wood et al., 2006; Pierce et al., 2012; Engström et al., 2013).

A general metabolic scheme for inorganic arsenic, illustrating the biotransformation in humans, is shown below in Figure 3-1. A more detailed discussion of inorganic arsenic pharmacokinetics is provided in Appendix D.

Figure 3-1 Biotransformation of inorganic arsenic in humans

Source: Sams et al. (2007)

### 3.1.1 Description of Pharmacokinetic Models

Physiologically based pharmacokinetic (PBPK) models for inorganic arsenic are important for describing exposure-internal dose relationships and, thus, informing dose-response estimates. The development of useful biologically-based dose-response models has proved to be challenging because inorganic arsenic can mediate its toxicity through a range of metabolites, and their roles with regard to specific adverse effects are not clear (Clewell et al., 2007). PBPK models have been developed specifically for inorganic arsenic exposure (Mann et al., 1996a; Yu, 1999; Mann et al., 1996b; Gentry et al., 2004; Gentry et al., 2005; Kenyon et al., 2008; El-Masri and Kenyon, 2008; El-Masri et al., 2018a; El-Masri et al., 2018b). These models were evaluated following methods in the ORD’s Quality Assurance Project Plan (QAPP) (L-CPAD-0032188-QP-1-2), and the El-Masri-Kenyon model was chosen as the most appropriate (see iAs Protocol, Appendix E [link provided in Appendix A]). In brief, the El-Masri-Kenyon model was selected because it incorporated more complex metabolic mechanisms with parameters that were independently derived from experimental and literature data (Kenyon, 2021).

The El-Masri-Kenyon model was then evaluated using two large data sets (~11,000 and 500 subjects in Bangladesh and Nevada, respectively) which provided matched individual chronic arsenic drinking water exposure and urinary excretion. Quantitative relationships between exposure in drinking water and urine levels of inorganic arsenic were developed for well-studied populations (Bangladesh, Taiwan, U.S., males and females) using age- and population-specific conversions in the dose estimates. The El-Masri-Kenyon model was considered to adequately predict measured data for the overall oral exposure to inorganic arsenic (El-Masri et al., 2018a; El-Masri et al., 2018b) (see Figure 3-2, Bangladesh data shown).

Figure 3-2 El-Masri-Kenyon PBPK model calibration against measured iAs total urinary concentrations and drinking water concentrations

Ultimately, the El-Masri-Kenyon PBPK model (El-Masri and Kenyon, 2008; El-Masri et al., 2018a; El-Masri et al., 2018b) establishes an approximate 1:1 empirical relationship between the total urinary arsenic mg/day excretion and the mg/day oral consumption of inorganic arsenic (see Table 3-1 below).

Table 3-1 Relationship between daily iAs dose and daily urinary tAs excretion

Daily iAs dose (mg/d) | Total As urinary excretion rate (mg/d)
0.001 | 9.5e−4
0.01 | 0.0095
0.02 | 0.019
0.04 | 0.038
0.05 | 0.048
0.1 | 0.095
0.15 | 0.143
0.3 | 0.29
1 | 0.95
1.5 | 1.42
2 | 1.9
10 | 9.2
50 | 45.2

## 3.2 EVIDENCE SYNTHESIS

This assessment focuses on cancer and noncancer outcomes including bladder cancer, lung cancer, DCS, fetal, newborn, and infant health outcomes, neurodevelopmental effects, and diabetes. The prioritization of these health outcomes was based on prior feedback from (NRC, 2009; NRC, 2013; NRC, 2014; NASEM, 2019) and availability of evidence. Because bladder cancer and lung cancer are accepted hazards of inorganic arsenic exposure (WHO, 2011a; NTP, 2016; Lynch et al., 2017a; IARC, 2004b; ATSDR, 2007; ATSDR, 2016), the strength of evidence for these health outcomes was considered robust, and no new evidence synthesis was conducted by EPA. This assessment focuses on studies for these outcomes considered most suitable for dose-response analysis. New evidence synthesis analysis was conducted for DCS; fetal, newborn, and infant health outcomes (i.e., fetal, and infant loss, fetal growth, prematurity, birth weight, and growth in the first 10 years of life); neurodevelopmental effects; and diabetes (see Section 1.6 and the Protocol for Assessment Methods).

Noncancer

### 3.2.1 Diseases of the Circulatory System

#### Database Overview

In 2013, the NRC concluded that low-to-moderate (<100 μg/L in drinking water) levels of inorganic arsenic are associated with cardiovascular disease based on evidence from human studies (NRC, 2013). As a result, evaluation of cardiovascular disease was recommended for consideration for dose-response analysis in the IRIS Toxicological Review. On the basis of the analysis of epidemiological evidence, the strength of evidence judgment for a causal association was considered “robust.” Robust evidence from humans leads to the strongest evidence integration conclusion of evidence demonstrates (U.S. EPA, 2022). This section summarizes the review of the available evidence demonstrating a conclusion that exposure to iAs causes diseases of the circulatory system.

There are 169 epidemiological publications that examined the relationship between iAs exposures and diseases of the circulatory system (see Figure 3-3). One hundred and twenty-two of these publications underwent study evaluation; 93 studies (including one study (Nigra et al., 2021) that was identified post-2019 and considered only for dose-response analysis) were considered medium or high confidence and the remaining 29 were considered low or uninformative. Forty-seven studies were identified post-2019 and were not considered further for hazard identification or dose-response (see Section 1.6.1). The study evaluations for all the epidemiologic studies are summarized in HAWC (https://hawc.epa.gov/summary/assessment/100500243/visuals/). Given the abundance of studies, the synthesis below focuses on conclusions from the high and medium confidence studies. Citations of studies broken down by confidence level, type of cardiovascular outcome, and studies identified in the 2022 update can be accessed via the interactive HAWC literature tag-tree visual presented in Figure 3-3.

Figure 3-3 Literature tree of epidemiological studies assessing diseases of the circulatory system (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Diseases-of-the-circulatory-system/))

In many of these studies, individual exposure was measured by using arsenic concentrations in drinking water to measure chronic and/or current exposure. The populations examined in the epidemiological studies were exposed to mean concentrations of iAs in drinking water over their lifetimes (or specified durations) ranging from <10 μg/L to approximately 930 μg/L. Other studies utilized biomarker measures of arsenic, such as in urine, toenail, hair, or blood. Strengths and weaknesses of biomarker and drinking water exposure assessment approaches are discussed in Section 1.6.2. The most informative studies for both water and biomarker exposure measures are those that included a range of concentrations and had adequate sample size across that range.

Studies conducted in southwest Taiwan are discussed separately within subsections, when available, due to their limited relevance to U.S. populations, where the average drinking water concentrations are 500-fold lower, and the highest concentrations observed are still 10- to 100-fold lower. Additionally, many of these studies are unique “natural experiments,” examining pre- and post-intervention arsenic exposures. For more background on this population see Section 1.6.2. Mechanistic observations are also summarized in this section.

Finally, this section discusses how an association between iAs, and CVD outcomes might be influenced by potential risk modifiers (e.g., environmental co-exposures, life stage, sex).

#### Evidence from Epidemiological Studies

For the purpose of defining the scope of this section, diseases of the circulatory system (DCS)^10^ include cardiovascular diseases (CVDs) such as ischemic heart disease (IHD) (known as coronary heart disease^11^), hypertension, cerebrovascular disease and stroke, and peripheral vascular diseases (PVDs). Studies describing inorganic arsenic exposure and related intermediate endpoints and/or risk factors for DCS are also considered.

Cardiovascular disease (CVD) is an umbrella term, referring to diseases of the heart and blood vessels. Among the most common CVD that is studied in relation to inorganic arsenic exposure is IHD, also called coronary heart disease. Typically, IHD refers to heart conditions caused by narrowed coronary arteries that supply blood to the heart muscle. When blood flow is completely blocked, tissue death in the heart occurs, which is known as a heart attack or myocardial infarction (MI). The literature base includes intermediate endpoints that are evaluated when making a CVD or IHD diagnosis, such as hypertension, atherosclerosis, and electrocardiogram abnormalities. The arsenic literature includes studies of exposure to inorganic arsenic and its association with hypertension, i.e., persistently elevated blood pressure, and/or subclinical changes in blood pressure metrics (e.g., systolic blood pressure, diastolic blood pressure, and pulse pressure). Hypertension is both a risk factor for CVD, IHD, and stroke, and is a heart disease that promotes left ventricular hypertrophy (LVH) and heart failure. QT prolongation, which is a repolarization abnormality that is associated with an overactivity in the sympathetic tone (Solti et al., 1989), frequently presents with LVH and is associated with an increased risk of sudden death. Stress induced increases in blood pressure are also consistent with sympathetic hyperreactivity and may indicate a potential trigger for hypertension.

The atherogenic effect of inorganic arsenic exposure can be studied by measuring carotid intima-media thickness (cIMT) using ultrasonography. It can also be studied by examining its relationship with biomarkers that indicate vascular inflammation or endothelial dysfunction (e.g., soluble intercellular adhesion molecule-1 [sICAM-1] and soluble vascular adhesion molecule-1 [sVCAM-1], plasma asymmetric dimethylarginine [ADMA]) and the interaction between inorganic arsenic exposure and genetic variants related to endothelial dysfunction. Cerebrovascular diseases such as ischemic stroke, which may result from an obstruction within a blood vessel that supplies oxygen to the brain, are also studied in relation to arsenic exposure.

Lastly, the literature on the health effects of endemic arsenic exposure in southwest Taiwan where the population was exposed to high arsenic concentrations (mean concentrations ranging from 700–930 μg/L) over decades, includes studies of Blackfoot disease, which is a PVD that is characterized by progressive arterial occlusion in the lower extremities and gangrene (Pan et al., 1993; Chen et al., 1988). Because of the potential for arsenic to affect the peripheral vascular system, epidemiologic studies of Raynaud’s phenomenon, and subclinical indicators of PVD as defined by ankle-brachial index and response to cold stress, have been conducted in a variety of populations.

#### Ischemic Heart Disease

The literature review identified 15 epidemiological studies that were considered medium or high confidence that evaluated the association between iAs exposure and ischemic heart disease (IHD). Fourteen of those studies are reviewed in this section. (One study (Nigra et al., 2021) was identified post-2019 and considered only for dose-response analysis.) Studies used different methods to determine IHD mortality or incidence; this included ICD codes, medical chart review by expert committee, electrocardiography (ECG) results and history of myocardial infarction, and death certificates adjudicated by an expert panel. All eligible studies that reported effect estimates (see Section 1.6.3) are summarized in Figure 3-4.

Figure 3-4 Study evaluation ratings for references evaluating ischemic heart disease (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Ischemic-heart-disease-heatmap/))

Some of the strongest evidence for an association between iAs exposure and IHD-related outcomes comes from prospective cohort and case-control studies with individual-level exposure data. These studies, from multiple countries in populations with different ethnic backgrounds and sociodemographic information, reported positive associations between iAs and IHD incidence and mortality. The consistency of positive findings across multiple studies that applied widely different analytical methods to diverse populations with prior iAs exposures strongly supports a causal relationship between iAs intake and IHD. This includes low-moderate exposure levels, such as the dose-dependent relationship between iAs exposure and IHD morbidity and mortality observed in Italy (D’Ippoliti et al., 2015) and the U.S. (Moon et al., 2013) where a substantial proportion of the population is exposed to iAs concentrations in drinking water that are less than 100 μg/L.

##### Case-control and cohort studies

The literature review identified 11 case-control and cohort medium or high confidence studies that evaluated the association between iAs exposure and IHD. Exposure measurements of arsenic included drinking water iAs measurements (Monrad et al., 2017; Lewis et al., 1999; James et al., 2015; Hsueh et al., 1998; Gong and O’Bryant, 2012; D’Ippoliti et al., 2015; Chen et al., 1996), and biomarkers including urine, plasma, and toenail (Yuan et al., 2017; Moon et al., 2013; Farzan et al., 2015a; Chen et al., 2011b), and using both water and biomarker measurements (Chen et al., 2011b).

Large prospective cohort studies reported significant associations between arsenic and IHD incidence and mortality, including a cohort of 3,575 rural American Indian men and women enrolled in the U.S. Strong Heart Study (Moon et al., 2013) and a cohort of 11,746 men and women in Bangladesh enrolled in the Health Effect of Arsenic Longitudinal Study (HEALS) (Chen et al., 2011b). In Moon et al. (2013) when the highest and lowest quartiles of urinary arsenic concentrations (>15.7 vs. <5.8 μg/g creatinine) were compared, the hazard ratio for IHD (coronary heart disease) was 1.71 (95% CI, 1.19 to 2.44; P for trend <0.001) (see Figure 3-5). The authors also found a statistically significant dose-response relationship of urinary arsenic concentrations with IHD incidence and mortality. In the HEALS cohort, Chen et al. (2011b) found a dose-response relation between exposure to arsenic in well water assessed at baseline and mortality from IHD and other heart disease; the hazard ratios in increasing quarters of arsenic concentration in well water (0.1–12.0, 12.1–62.0, 62.1–148.0, and 148.1–864.0 μg/L) were 1.00 (reference), 1.22 (0.65 to 2.32), 1.35 (0.71 to 2.57), and 1.92 (1.07 to 3.43) (P = 0.0019 for trend), respectively (see Figure 3-5).

Both studies are limited in that they measured urinary arsenic levels in a single sample at baseline. However, Moon et al. (2013) cited evidence for the temporal stability of arsenic levels in drinking water (Steinmaus et al., 2005; Ryan et al., 2000; Karagas et al., 2001a) and in urine (Navas-Acien et al., 2009b; Karagas et al., 2001a) with long-term constancy in arsenic concentrations for upwards of 10 years. Chen et al. (2011b) observed positive associations of both baseline exposure to iAs in drinking water and concentration in urine with IHD-related mortality.

A number of studies examined arsenic exposure using arsenic concentration in well water and duration of drinking water in a highly exposed population of southwestern Taiwan. In Chen et al. (1996), a case-control study, cases were those with Blackfoot disease and controls were without Blackfoot disease, in order to examine IHD mortality. Significant associations with IHD mortality were observed for arsenic-exposure indices, including average arsenic concentration in drinking water and cumulative exposure from drinking artesian well water (relative risks: 2.5, 4.0, and 6.5 for those with cumulative arsenic exposure of 0.1–9.9, 10.0–19.9, and ≥20.0 mg/L-years, respectively, compared with those without arsenic exposure) (Chen et al., 1996). Also in southwestern Taiwan, Hsueh et al. (1998) observed an association between duration of consumption of high arsenic artesian well water and risk of IHD (OR (95% CI): 2.55 (1.02–6.37) and 2.89 (1.01–8.29) for those who consumed the water for 13–29 and ≥30 years, respectively, compared with those who consumed the water for <13 years).

A case-cohort study, which examined exposure to iAs in drinking water using a geospatial model of arsenic concentrations combined with residential histories in the San Luis Valley Diabetes Study in Colorado, U.S. to calculate lifetime exposure (James et al., 2015). The study population (n = 555) was exposed to iAs concentrations in drinking water ranging from 10 to 100 μg/L; hazard ratios were exposure-dependent, increasing with increasing time-weighted average lifetime exposure (IHD risk HR = 1.38, 95% CI: 1.09, 1.78 per 15 μg/L). Consistent results were seen in other studies from the U.S. In Texas, Gong and O’Bryant (2012) used ArcGIS inverse distance weighted interpolation of groundwater concentration in each study participant’s home (range: 2.2 – 15.3 μg/L (mean 6.2)), finding that coronary heart disease was associated with low-level arsenic exposure [OR (95% CI): 1.10 (1.00–1.21)]. In a European study that used a similar exposure assessment strategy, D’Ippoliti et al. (2015) followed residents of 17 municipalities in Italy (n = 165,609) to determine the association between iAs exposure and cause-specific mortality. Study participants were followed from 1990 to 2010 and exposed, on average, to 19.3 μg/L for 39.5 years. Metrics indicating average iAs exposure during the first year of residence and cumulative iAs exposure were derived by linking each study participant’s geocoded residential history to data on iAs concentration in drinking water. Associations of both exposure metrics with IHD and coronary atherosclerosis were observed in males and in females after adjustment for age, calendar period, socioeconomic status, smoking (municipal-level sales), and radon exposure (municipal level). Monrad et al. (2017) examined the association of 20-year TWA arsenic concentration in drinking water, which was similarly estimated by linking water supply measurements with geocoded residential addresses, and the risk of MI among participants in the Danish Diet, Cancer and Health cohort. The concentration of arsenic levels in drinking water at the participants’ baseline address ranged from 0.03 to 25.34 μg/L (median: 0.70 μg/L). No association between 20-year average concentration and MI was observed among the study population overall. An association between ever compared with never living at a residence with ≥10 μg/L was observed, however [IRR: 1.26 (95% CI: 0.89–1.79)].

A toenail biomarker study conducted in the U.S. (Farzan et al., 2015a) provides additional supporting evidence that arsenic is a contributing risk factor for IHD, particularly among long-term smokers. The use of toenails is advantageous in that they reflect inorganic arsenic exposure alone; however, external contamination by iAs that binds to the surface of nails as a result of contact with arsenic in the water prior to or during processing and analysis is a concern (NRC, 1999). Farzan et al. (2015a) conducted a longitudinal analysis of data from the population-based New Hampshire Skin Cancer Study. Investigators measured iAs concentration in toenail clippings (median (range): 0.09 (0–3.26) ppm) to determine the association of iAs exposure with IHD-related mortality. The mean arsenic level in home water supplies of study participants was 2.6 μg/L (range 0–158.1 μg/L). They reported no significant increase in HRs with increasing toenail arsenic concentration with IHD-related mortality for the overall study population after adjusting for skin cancer status, educational attainment, and pack-years of smoking. However, they observed positive associations for IHD mortality among current smokers [HR: 1.69 (95% CI: 1.04, 2.75)] and those reporting ≥31 years of smoking [HR: 1.52 (95% CI: 1.02, 2.27)] or ≥30 [HR: 1.66 (95% CI: 1.12, 2.45)] pack-years of smoking. Further, an increasing trend in RRs for toenail arsenic and IHD mortality has been reported for this cohort when grouped into exposure categories of 0.01–0.07 (reference group), 0.07–0.11 [RR: 1.13 (95% CI: 0.77, 1.67)] and 0.11–3.26 [RR: 1.22 (95% CI: 0.82, 1.82)] μg As/g toenail (Moon et al., 2017b).

A nested case-control study of Chinese adults (Dongfeng-Tongji Cohort), Yuan et al. (2017) examined the association of plasma arsenic concentration with incident IHD events (i.e., nonfatal MI, fatal IHD, stable and unstable angina, or coronary revascularization) confirmed by physician adjudication. Blood samples were obtained between 2008 and 2010 and follow-up exams were conducted in 2013. Authors observed a positive association in fully adjusted models [HR 1.78 (95% CI: 1.29, 2.46) comparing the highest to the lowest quartile (>3.49 μg/L vs. <1.28 μg/L) of plasma arsenic concentration].

Figure 3-5 Thumbnail schematic of case-control and cohort studies examining the association between IHD and inorganic arsenic exposure (a) ratio measures, biomarkers, categorical exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/DCS-IHD-case-controlcohort-ratios-biomarkers-2c41/), (b) ratio measures, drinking water, categorical exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/DCS-IHD-case-controlcohort-ratios-water-categ-9182/) (see interactive data graphics)

(a) Ratios measures, biomarkers, categorical exposure

(b) Ratio measures, drinking water, categorical exposure

##### Cross-sectional studies

One cross-sectional study of medium confidence examined the association between arsenic exposure and IHD (Tseng et al., 2003). In the U.S., Tseng et al. (2003) found OR (95% CI) for IHD was 3.60 (1.11, 11.65) for those with ≥15.0 mg/L-years consuming artesian well water, when compared with those with zero years of consuming artesian well water.

##### Ecological studies

Two ecological studies of medium confidence were included, which examined IHD-related mortality (Tsai et al., 1999; Smith et al., 2012). In Taiwan, Tsai et al. (1999), observed a statistically significant positive association for IHD mortality for both males (SMR: 1.75, 95% CI: 1.59–1.92) and females (SMR: 1.44, 95% CI: 1.27–1.61) (median arsenic in artesian wells = 780 ppb). Statistically significant positive associations were observed for acute myocardial infarction mortality in Chile (Smith et al., 2012).

###### Natural experiment: Highly exposed population in southwest Taiwan

Studies mentioned here have been discussed previously in their respective study design sections and are also briefly discussed here together for additional context. The studies reporting the strongest exposure-dependent positive associations examined the effect of cumulative arsenic exposure ([mg/L*yr]) on IHD-related morbidity or mortality in the southwestern coastal region of Taiwan, where chronic arsenic poisoning was endemic (Tseng et al., 2003; Tsai et al., 1999; Hsueh et al., 1998; Chen et al., 1996). The average drinking water concentrations in the U.S. are 500-fold lower, with even the highest concentrations observed 10- to 100-fold lower than those within the Taiwan study population Residents of Southwest Taiwan were exposed to arsenic in drinking water at concentrations of 700–930 μg/L over decades, until the use of drinking water wells containing high concentrations of arsenic was discontinued in the mid-1970s. Community level interventions to stop use of these wells created natural experiments. Some ecological studies also included unique design features that took advantage of natural experiments with exposure periods having documented beginnings, endings, or both, allowing for examination of pre- and post-intervention cardiovascular mortality rates.

##### Supplemental information: Meta-analyses

Moon et al. (2017b) updated prior meta-analyses of CVD health outcomes by Moon et al. (2012)^12^ and Navas-Acien et al. (2006). The Moon et al. (2017b) meta-analyses used criteria including from the Newcastle-Ottawa Scale (https://www.ohri.ca/programs/clinical_epidemiology/oxford.asp) to assess study quality to estimate the relationship between levels of arsenic in drinking water and relative risks for incidence of and fatality from clinical CVD endpoints (all CVD, CHD, and stroke) in the adult general population. They excluded studies of childhood exposures, occupational exposures uncommon in the general population (e.g., arsenic trioxide), case reports or case series, preclinical CVD outcomes, ecological studies (or studies analyzed as group-level data), studies with prevalent outcomes, and studies that reported results with fewer than three exposure categories. Their approach was similar to EPA’s dose-response meta-analysis (see Section 4.3.7). Moon et al. (2017b)^13^ reported the summary effect estimates in these meta-analyses, which supported a positive association between chronic high levels of arsenic in drinking water and IHD. Compared with 10 mg/l, the estimated pooled relative risks [95% confidence interval (CI)] for 20 mg/l water arsenic were 1.11 (1.05, 1.17) for CHD incidence, and 1.16 (1.07, 1.26) for CHD mortality.

##### Summary

Overall, epidemiological studies provide robust evidence for exposure-dependent associations between arsenic exposure and both IHD incidence and mortality. As discussed in the protocol (link provided in Appendix A) and supported by the NASEM (NASEM, 2019), this is consistent with associations noted in other assessments (ATSDR, 2007; ATSDR, 2016; WHO, 2011b; WHO, 2011a). The study designs most informative to this question, prospective cohort and case-control studies with individual-level exposure data from multiple countries in populations with different ethnic backgrounds and sociodemographic information, demonstrate consistently elevated IHD in association with iAs exposure. At least one dose-response gradient association was observed in almost every study, covering both incidence and mortality, (Yuan et al., 2017; Moon et al., 2013; James et al., 2015; Hsueh et al., 1998; D’Ippoliti et al., 2015; Chen et al., 1996; Chen et al., 2011b), and large effect estimates that gain statistical significance at higher exposure levels, with many studies conducted in areas with lower levels of drinking water arsenic exposure (<100 μg/L (including <20 μg/L) ). Further supporting these findings are cross-sectional and ecological studies, “natural experiment” studies from southwest Taiwan, and meta-analyses.

#### Cardiovascular Disease

The literature review identified 12 epidemiological studies that were considered medium or high confidence that evaluated the association between iAs exposure and cardiovascular disease and mortality. Cardiovascular disease was identified by methods including review of hospitalization or death records adjudicated by expert committee, and death certificates verified for ICD coding by a nosologist. All eligible studies that reported effect estimates (see Section 1.6.3) are summarized in Figure 3-6.

Figure 3-6 Study evaluation ratings for references evaluating cardiovascular disease (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Cardiovascular-disease-heatmap/))

##### Case-control and cohort studies

The literature review identified eight case-control and cohort medium or high confidence studies (Wade et al., 2009; Wade et al., 2015; Sohel et al., 2009; Moon et al., 2013; Liao et al., 2012; Lewis et al., 1999; Farzan et al., 2015a; Chen et al., 2013c) that evaluated the association between iAs exposure and cardiovascular disease. Exposure measurements of arsenic included drinking water iAs measurements (Lewis et al., 1999; Wade et al., 2009; Sohel et al., 2009; Liao et al., 2012; Wade et al., 2015); biomarkers including urine, hair, and toenail (Chen et al., 2013c; Moon et al., 2013; Wade et al., 2015; Farzan et al., 2015a), and using both water and biomarker measurements (Wade et al., 2015; Chen et al., 2013c).

Two large prospective cohort studies with urinary arsenic concentrations, a cohort of 3,575 rural American Indian men and women enrolled in the U.S. Strong Heart Study (Moon et al., 2013) and a cohort of 11,746 men and women in Bangladesh enrolled in the Health Effect of Arsenic Longitudinal Study (HEALS) (Chen et al., 2011b), reported significant associations with CVD incidence and mortality and total arsenic or its metabolites. In the Strong Heart Study, Moon et al. (2013) found chronic exposure to arsenic was associated with CVD incidence and mortality. When the highest and lowest quartiles of arsenic concentrations (>15.7 vs. <5.8 μg/g creatinine) were compared in Moon et al. (2013), the hazard ratio for cardiovascular disease was 1.65 (95% CI, 1.20 to 2.27; P for trend <0.001) (see Figure 3-7b). The authors also found a statistically significant dose-response relationship of urinary arsenic concentrations with CVD incidence and mortality. Chen et al. (2011b) found changes in urinary arsenic over time were positively associated with risk of mortality from total cardiovascular disease. There was a dose-response relationship between exposure to arsenic in well water (mean = 63.5 μg/L), which was also measured in HEALS, assessed at baseline and mortality from heart disease. Also conducted in HEALS, a case-cohort analysis (well arsenic range: 0.1–864 μg/L) reported increased risk of CVD-related mortality among those with lower methylation capacity (Chen et al., 2013c).

In the highly exposed population of southwestern Taiwan (artesian well water arsenic concentration range: 35–1140 ppm; median 780 ppm), an association was reported between cumulative arsenic exposure (ppm-years) and abnormal lactate dehydrogenase activity, a marker of CVD risk (Liao et al., 2012).

Studies examining drinking water arsenic concentrations from other countries were consistent with the southwestern Taiwan findings. In a cohort from an Inner Mongolian village, heart disease mortality was observed to be associated with arsenic exposure, as measured by well water arsenic exposure among those exposed for 10–20 years (Wade et al., 2009). In Bangladesh, similar findings of excess mortality due to cardiovascular disease were seen (Sohel et al., 2009).

In the U.S., in Utah, Lewis et al. (1999) used residence history and median drinking water arsenic concentration (range: 14 – 166 μg/L), authors observed increased mortality from hypertensive heart disease.

In a toenail biomarker assessment, Wade et al. (2015) conducted a hospital-based, case-control study in Inner Mongolia using arsenic concentrations in toenail clippings and arsenic concentration measured at each participant’s primary drinking water source as exposure metrics. As shown in Figure 3-7, arsenic concentrations in drinking water and toenails were associated with increased CVD incidence. The drinking water arsenic concentration ranged from less than the limit of detection (average 0.16 μg/g) to 208 μg/L (mean 8.9 μg/L) among study participants.

Figure 3-7 Thumbnail schematic of case-control and cohort studies with CVD outcomes in relation to inorganic arsenic exposure (a) ratio measures, drinking water, categorical exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/DCS-CVD-case-control-ratios-drinking-water-categor/), (b) ratio measures, biomarkers, categorical exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/DCS-CVD-casecontrol-ratio-biomarker-categorical/) (see interactive data graphics)

(a) Ratio measures, drinking water, categorical exposure

(b) Ratio measures, biomarkers, categorical exposure

##### Cross-sectional studies

Two cross-sectional studies of medium confidence examined the association between arsenic exposure and CVD outcomes in Turkey and Taiwan, respectively (Gunduz et al., 2017; Zierold et al., 2004). Both received a deficient rating for the exposure assessment domain due to concerns over using self-collected water samples, self-reported residential history, and self-reported duration of well water consumption as surrogates for exposure. However, since the exposures to arsenic from drinking water were shown to be long-term, there is confidence in the temporality of exposure and disease occurrence. Zierold et al. (2004) found a statistically significant association between water arsenic exposure (As >10 μg/L compared with As <2 μg/L) and heart attack (OR (95% CI): 2.08 (1.10, 4.31)). Gunduz et al. (2017) examined the distribution of chronic diseases in villages with high arsenic levels in drinking water supplies in Turkey (range: 27–177.2 μg/L) and found diseases of the circulatory system to have the highest prevalence compared to other chronic diseases (including diseases of the nervous system; respiratory system; digestive system; musculoskeletal system).

##### Ecological studies

Two ecological studies of medium confidence were included, examining CVD-related mortality in Taiwan, and Spain, respectively (see Figure 3-8) (Tsai et al., 1999; Medrano et al., 2010). Statistically significant positive associations were observed for heart disease mortality in Taiwan (median arsenic in artesian wells = 780 ppb) and CVD mortality in Spain (mean municipal drinking water arsenic concentrations ranged from <1 to 199 μg/L).

Figure 3-8 Thumbnail schematic of ecological epidemiological studies addressing the association between iAs exposure and CVD mortality (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/DCS-CVD-ecological-drinkingwater-categoricalexposu/) (see interactive data graphic)

##### Supplemental information: Meta-analyses

Moon et al. (2017b) updated prior meta-analyses of CVD health outcomes by Moon et al. (2012)^14^ and Navas-Acien et al. (2006). The Moon et al. (2017b) meta-analyses used criteria including from the Newcastle-Ottawa Scale (https://www.ohri.ca/programs/clinical_epidemiology/oxford.asp) to assess study quality to estimate the relationship between levels of arsenic in drinking water and relative risks for incidence of and fatality from clinical CVD endpoints (all CVD, CHD, and stroke) in the adult general population. They excluded studies of childhood exposures, occupational exposures uncommon in the general population (e.g., arsenic trioxide), case reports or case series, preclinical CVD outcomes, ecological studies (or studies analyzed as group-level data), studies with prevalent outcomes, and studies that reported results with fewer than three exposure categories. Their approach was similar to EPA’s dose-response meta-analysis (see Section 4.3.7). Moon et al. (2017b)^15^ reported the summary effect estimates in these meta-analyses, which supported a positive association between chronic high levels of arsenic in drinking water and multiple CVD endpoints (all CVD, stroke). Compared with 10 μg/l, the estimated pooled relative risks [95% confidence interval (CI)] for 20 μg/l water arsenic were 1.09 (1.03, 1.14) for CVD incidence, 1.07 (1.01, 1.14) for CVD mortality, and 1.08 (0.99, 1.17) for stroke incidence.

##### Summary

Overall, epidemiological studies provide robust evidence for exposure-dependent associations between arsenic exposure and cardiovascular disease. As discussed in the protocol (link provided in Appendix A) and supported by the (NASEM, 2019), this is consistent with associations noted in other assessments (ATSDR, 2007; ATSDR, 2016; WHO, 2011b; WHO, 2011a). The study designs most informative to this question, prospective cohort and case-control studies with individual-level exposure data from multiple countries in populations with different ethnic backgrounds and sociodemographic information, demonstrate consistently elevated CVD-related outcomes in association with iAs exposure, dose-response gradient associations observed in some studies [e.g., (Wade et al., 2015; Moon et al., 2013; Medrano et al., 2010; Chen et al., 2013c)], large effect estimates that gain statistical significance at higher exposure levels, and coherence across markers of disease. Further supporting these findings are cross-sectional studies, ecological studies, and meta-analyses.

#### Intermediate Endpoints and/or Risk Factors for Ischemic Heart Disease and Cardiovascular Disease

This section describes the consistent associations that have been observed between arsenic exposure and intermediate endpoints that are evaluated when making a CVD or IHD diagnosis. Studies will be discussed by study design under each intermediate endpoints reviewed: hypertension, atherosclerosis, and electrocardiogram abnormalities.

##### Hypertension and increased blood pressure

The literature review identified 31 epidemiological studies, 12 case-control/cohort (Yu et al., 2017; Wang et al., 2011; Rahman et al., 1999; Newman et al., 2016; Lewis et al., 1999; Jiang et al., 2015; Huang et al., 2007; Hawkesworth et al., 2013; Hall et al., 2017; Gong and O’Bryant, 2012; Farzan et al., 2015b; Farzan et al., 2015c) and 19 cross-sectional studies (Zierold et al., 2004; Wei et al., 2017b; Wei et al., 2017a; Skröder et al., 2015; Rahman and Axelson, 2001; Osorio-Yáñez et al., 2015; Li et al., 2013b; Li et al., 2013a; Li et al., 2015; Kwok et al., 2007; Kunrath et al., 2013; Jones et al., 2011; Islam et al., 2012a; Hossain et al., 2017; Guha Mazumder et al., 2012; Chen et al., 1995; Chen et al., 2007; Chen et al., 2012b; Ameer et al., 2015), considered medium or high confidence that evaluated the association between iAs exposure and hypertension (see Figure 3-9). Hypertension is usually defined as systolic blood pressure (SBP) ≥140 mmHg and diastolic blood pressure (DBP) ≥90 mmHg. The condition can promote left ventricular hypertrophy and heart failure and is a risk factor for CHD and stroke. Studies also examine changes in SBP, DBP and pulse pressure, which is the difference between SBP and DBP and a risk factor for heart disease and stroke. The results from studies of hypertension are summarized in Figure 3-10 and Figure 3-11.

Figure 3-9 Study evaluation ratings for references evaluating hypertension and increased blood pressure (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Hypertension/))

Since hypertension can resolve in the absence of exposure the studies included in the plot below should be interpreted in the context of the temporal relationship of the exposure (e.g., the appropriateness of the exposure metric) and the ascertainment of the outcome. While prospective cohort studies are generally better able to establish temporality, cross-sectional studies were found to be informative for blood pressure effects associated with concurrent exposures to arsenic. Many cross-sectional studies were able to infer temporality in that arsenic exposure was relatively stable over time, such as in drinking water and urinary arsenic samples (median(IQR): 8.3 μg/L (4.2–17.1)) in the U.S. (NHANES) (Jones et al., 2011), and in southwest Taiwan where long-term exposure was identified by sampling in previously-Blackfoot disease endemic areas (median arsenic concentration of the artesian well water ranged from: 700–930 μg/L) (Chen et al., 1995) (see Figure 3-11).

Several studies examined the relationship between inorganic arsenic exposure and hypertension in cohorts in Bangladesh. In a retrospective cohort analysis, both water concentrations (i.e., >50 μg/L) and cumulative arsenic concentration (i.e., >5 mg-y/L) were associated with hypertension in four villages in the districts of Faridpur, Nawabgong, Bangladesh, Jessore, and Narayongong (Rahman et al., 1999) (see Figure 3-10). Although arsenic concentrations were not measured and assigned to individuals in this study, previous measurements indicated that more than 50% of wells had arsenic concentrations greater than 50 μg/L and eligible participants (≥30 years old) were exposed for their entire lifetime. Further, in a subsequent cross-sectional analysis of this cohort (drinking water arsenic concentration range: nondetectable – 2040 μg/L) the risk of hypertension was higher among those with skin lesions related to arsenic exposures compared with those without skin lesions (Rahman and Axelson, 2001). By contrast, in a cross-sectional study conducted in other areas of Bangladesh (i.e., Comilla, Jhenidah, Kalinganj districts) where arsenic concentrations in drinking water ranged from 10–1,400 μg/L, Islam et al. (2012a) reported an association of arsenic exposure with pulse pressure (PP) but not with hypertension (see Figure 3-13). In another cross-sectional study, Hossain et al. (2017) observed chronic arsenic drinking water exposure (mean(SD): 17.76 μg/L (15.16)) inversely associated with LINE-1 methylation levels, which may be involved with elevated BP. Additional analyses focusing on sensitive subgroups and subclinical increases in blood pressure (e.g., SBP, DBP, and pulse pressure [PP]) are discussed below and provide additional context for the main effects observed in the hypertension studies.

Figure 3-10 Thumbnail schematic of case-control/cohort studies of hypertension in response to inorganic arsenic exposure (a) ratio measures, drinking water, categorical exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/DCS-hypertension-case-controlcohort-categoric-e42a/); (b) difference measures, urine, continuous exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/DCS-hypertension-case-controlcohort-urine-cat-3387/update/) (see interactive data graphic)

(a) Ratio measures, drinking water, categorical exposure

(b) Difference measures, urine, continuous exposure

Figure 3-11 Thumbnail schematic of cross-sectional studies of hypertension in response to inorganic arsenic exposure (a) ratio measures, urine, categorical exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/DCS-hypertension-cross-section-urine-categori-a741/); (b) ratio measures, drinking water, categorical exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/DCS-hypertension-cross-sectional-water-catego-5d11/); (c) difference measures, urine, continuous exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/DCS-hypertension-cross-sectional-ratios-water-c50d/) (see interactive data graphics)

(a) Ratio measures, urine, categorical exposure

(b) Ratio measures, drinking water, categorical exposure

(c) Difference measures, urine, continuous exposure

In Bangladesh, the association of inorganic arsenic exposure and hypertension was examined in a cross-sectional study among participants in the HEALS cohort, a large study (n = 11,746) of adults (≥18 years old) who lived in the study area for at least 5 years. Water samples and location data were collected for approximately 6,000 wells in the study area, and individual-level data on a large number of covariates including nutritional status were ascertained. No association of time-weighted average exposure to arsenic (range: 0.1–864.0 μg/L) with general hypertension was reported among HEALS participants (Chen et al., 2007) (see Figure 3-13). Associations with PP were observed, however, and subgroup analyses indicated that effect of arsenic on blood pressure was discernable among those with longer-duration exposures (≥5 years to known concentrations of iAs in drinking water) and lower nutrient intake (e.g., vitamin B and folate). Subsequent analyses of the data from this cohort reported associations of baseline concentration of arsenic in water (median: 62 μg/L) and arsenic concentration in urine (median: 88 μg/L) with small statistically significant annual increases in both SBP and DBP (Jiang et al., 2015). Wei et al. (2017b) reported an increase in SBP and DBP in association with cumulative arsenic exposure (range: <10–824.70 μg/L) in Inner Mongolia, China. Modification of the longitudinal association of water arsenic concentration with blood pressure (well water arsenic in those with normal (<120 mm Hg) SBP, mean(SD): 102.0 (115.9); well water arsenic in those pre-hypertensive to hypertensive (≥120 mm Hg), mean(SD): 91.9 (104.5) by genes related to methylation capacity, oxidative stress, and endothelial dysfunction was also observed among HEALS participants (Farzan et al., 2015c). Wei et al. (2017a) further reported a higher prevalence of hypertension among those with arsenic-associated skin lesions compared with those without arsenic-associated skin lesions in Inner Mongolia, China (water arsenic concentrations ranged from (means) 114.00–203.77 μg/L across skin lesion groups) (see Figure 3-13).

Hall et al. (2017) used data from a population-based case-control study of cancer in northern Chile to conduct an analysis of the relationship between highest lifetime 5-year average arsenic concentration and hypertension (self-reported physician diagnosed hypertension or use of anti-hypertensive medications ascertained between 2007 and 2010). Study participants may have been exposed to concentrations greater than 860 μg/L in drinking water prior to the implementation of alternative drinking water sources in the 1970s. Arsenic exposure was positively associated with hypertension in this study [OR: 1.49 (95% CI: 1.09, 2.05) and 1.65 (95% CI: 1.18, 2.32), comparing the middle and upper tertile of 5-year average arsenic concentration to the reference category of <60 μg/L]. Arsenic exposure estimated based on the sum of arsenic metabolite concentrations in urine, was associated with decreased SBP and DBP among women (18–65 years of age) in northern Argentina (Ameer et al., 2015), however. Concentrations of arsenic in drinking water ranged from 10 to 200 μg/L in the villages studied.

The association of inorganic arsenic exposure with hypertension was also studied in several cohorts in northern China (Inner Mongolia). Li et al. (2013a) found dose-dependent associations between iAs in water and prevalent hypertension (OR: 1.47 (0.767, 2.618) comparing group with water concentrations from 10–50 μg/L to the reference category (i.e., <10 μg/L) and OR: 1.94 (95% CI: 1.018, 3.687) comparing the group with >50 μg/L to the reference in adjusted models (see Figure 3-13). Participants in this study were recruited from villages where interventions to reduce arsenic exposure in drinking water had not occurred and concentrations ranged from 0–760 μg/L. Consistent findings were also seen in an additional Chinese cohort, which observed an association between hair arsenic concentration and hypertension risk (Yu et al., 2017). An exposure-dependent pattern of associations was shown in another cohort in Inner Mongolia [OR: 1.204(95% CI: 0.632, 2.292) and OR: 1.871(95% CI: 1.022, 3.424) comparing the second (0.10–0.35 mg/L-year) and third (>0.35 mg/L) tertiles to the reference category (<0.10 mg/L-year), respectively] (Li et al., 2013b) (see Figure 3-13). A similar pattern of associations of iAs and iAs % in urine and hypertension were observed, and low methylation capacity indicated by a higher percentage of monomethylarsonic acid (MMA) in urine was also associated with hypertension in another Inner Mongolia, China study from this author (Li et al., 2015). In Taiwan, exposure to high levels of arsenic in artesian well water was associated with hypertension (Wang et al., 2011).

Finally, U.S. studies show positive associations with markers of arsenic exposure in urine (Jones et al., 2011) and drinking water concentrations greater than 10 that were estimated by linking ground water arsenic concentrations to geocoded residential address (Gong and O’Bryant, 2012). Jones et al. (2011) examined a representative U.S. population of participants in the National Health and Nutrition Examination Survey [NHANES], reporting a null associations per doubling of total iAs in urine (categorical results presented in Figure 3-13). A positive association of DMA with hypertension (OR: 1.11 (95% CI: 0.99–1.24] per doubling) was observed, however. GIS estimated arsenic concentrations in drinking water (range: 2.2–15.3 μg/L (mean 6.2)) was associated with hypertension (OR: 1.10 [95% CI: 1.03, 1.17]) in a study in rural Texas where arsenic concentrations have been found to be elevated (Gong and O’Bryant, 2012). In another cross-sectional study, Kunrath et al. (2013) reported stress-induced increases in both SBP and DBP associated with drinking water arsenic exposure (mean: 40.2 μg/L) in normotensive men in Romania (see Figure 3-13). This finding is consistent with a role for sympathetic hyperreactivity in arsenic-associated hypertension risk. Additional U.S. studies observed an association between urinary arsenic concentration (median(IQR): 9.9 μg/g creatinine (6.0–15.7)) and peripheral arterial disease markers in American Indians (Newman et al., 2016); arsenic in drinking water (range: 14–166 μg/L) and mortality from hypertensive heart disease in residents from Utah (Lewis et al., 1999); and arsenic in private well water (range: 14–166 μg/L) and high blood pressure (Zierold et al., 2004).

###### Supplemental information: Meta-analysis

Abir et al. (2012) conducted a meta-analysis examining the relationship between chronic arsenic exposure and hypertension. Seven cross-sectional studies and one cohort study that met their inclusion criteria were analyzed. On the basis of pooling of extracted odds ratios for the highest and lowest exposure categories in each study, they reported an OR of 1.9 (95% CI: 1.2–3.0) when using arsenic concentration in drinking water as the exposure metric, and an OR of 1.4 (95% CI: 0.95–2.0) when using arsenic concentration and duration as the exposure metric. These two meta-analyses provide evidence for a relationship between arsenic exposure and hypertension, although limited by imprecision due to the small sample sizes and heterogeneity in effect estimates across studies.

###### Pregnancy and early childhood exposures

Several studies examined the effect of exposure to iAs during pregnancy or early childhood on blood pressure. In a prospective cohort study of pregnant women in New Hampshire (well water concentration mean(SD): 4.3(11.0) μg/L), each 5 μg/L increase in urinary As concentration at baseline was associated with a 0.15 mmHg (95% CI: 0.02, 0.29) increase in systolic blood pressure per month and a 0.14 mmHg (95% CI: 0.02, 0.25) increase in pulse pressure per month (Farzan et al., 2015b). No association with DBP was observed. Farzan et al. (2015b) derived several metrics to indicate methylation capacity (i.e., concentration of MMA and dimethylarsenic acid [DMA] in urine, which are indices of primary and secondary methylation) but did not report strong evidence that the effect of arsenic exposure was increased among those with lower methylation capacity. In a study conducted among women of reproductive age in Inner Mongolia, Kwok et al. (2007) reported that higher SBP and DBP were associated with increasing quartiles of arsenic concentration (≤20 [reference group], 21–50, 51–100, and >100 μg/L) in drinking water. DBP increased by a smaller increment than SBP did for the same quartile increase of arsenic concentration. Information on potential confounders was unavailable for more than half the study population, however, and potential confounding was indicated in a sensitivity analysis comparing results for those with and without covariate information.

Hawkesworth et al. (2013) conducted a follow-up study of children in rural Bangladesh to evaluate the effect of nutrient supplementation on birth outcomes. The sum of iAs and its metabolites in urine during early (weeks 8–12) and late (weeks 30–33) gestation and in infants 18 months of age was assessed relative to blood pressure at 4.5 years of age. Each 1 mg/L of urinary arsenic during gestation was associated with increased SBP (3.69 mmHg [95% CI: 0.74–6.63] per mg/L increase in urinary arsenic) and DBP (2.91 mmHg [95% CI: 0.41–5.42]). A 1 mg/L urinary arsenic concentration at 18 months of age (median (IQR): 33.9 μg/L (18.2, 77.4)) was associated with an 8.25 mmHg (95% CI: 1.37, 15.1; p = 0.02) increase in systolic blood pressure at 4.5 years. The study authors did not find any interaction with nutrient supplementation. However, in a subsequent cross-sectional study based on children from the same cohort, no associations of current urinary arsenic (median (IQR): 54 μg/L (16, 343)) with SBP and DBP were observed in multivariable models simultaneously adjusted for cadmium and selenium (Skröder et al., 2015). This differs from the previous observation for this cohort. The change could be due to ongoing exposure mitigation in the area, decreased sensitivity of this age group and/or the model adjustment for cadmium and selenium (Skröder et al., 2015), both of which showed a slight positive association with increasing SPB and DPB. Osorio-Yáñez et al. (2015) reported cross-sectional associations of total arsenic concentration in urine with increased SBP and DBP among children 3–8 years of age in Mexico. In addition, duration of water consumption was associated with increased left ventricular mass in this study, providing further indirect support for arsenic-associated changes in blood pressure. In 2009, drinking water arsenic concentrations ranged from 3 to 135 μg/L in the study area. From 1993 to 2009, the iAs concentrations in the water ranged from 3 to 398 μg/L. Study subjects were recruited in 2009.

###### Summary

Exposure-dependent associations of arsenic exposure (drinking water concentrations, cumulative exposure, and biomarkers or arsenic or its metabolites in urine) with prevalent hypertension are generally observed across epidemiologic studies. A dose-response gradient was observed in many studies [e.g., (Zierold et al., 2004; Wang et al., 2011; Rahman et al., 1999; Li et al., 2013b; Li et al., 2013a; Li et al., 2015; Jones et al., 2011; Islam et al., 2012a; Hawkesworth et al., 2013; Hall et al., 2017; Guha Mazumder et al., 2012)]. This evidence indicates that the effect of arsenic exposure on hypertension and blood pressure might be more pronounced among those with higher exposure (>100 μg/L), longer-duration exposures, lower methylation capacity, or lower nutrient intake. Studies also show consistent associations with increased systolic blood pressure or pulse pressure in adults, pregnant women, and children.

##### Atherosclerosis

The literature review identified 16 epidemiological studies, 6 case-control/cohort (Wu et al., 2006; Wu et al., 2010b; Wang et al., 2002; Wang et al., 2007; Wang et al., 2010; Hsieh et al., 2008b) and 10 cross-sectional studies (Wang et al., 2009; Velmurugan et al., 2018; Stea et al., 2016; Osorio-Yáñez et al., 2013; Nong et al., 2016; Mateen et al., 2017; Li et al., 2009; Chiou et al., 2001b;Chen et al., 2006; Chen et al., 2013b), considered medium or high confidence that evaluated the association between iAs exposure and atherosclerosis (see Figure 3-12). Coronary atherosclerosis is typically clinically assessed using ultrasonography to measure cIMT where a cIMT ≥1 mm or the presence of observable plaque is typically considered atherosclerosis. However, different definitions of atherosclerosis are used in the iAs evidence base and atherosclerosis severity might or might not have been classified.

Figure 3-12 Study evaluation ratings for references evaluating atherosclerosis (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Atherosclerosis/))

The epidemiological studies presented in Figure 3-13 and Figure 3-14 report generally consistent exposure-dependent associations for iAs with atherosclerosis. Cumulative exposure to iAs among the highly exposed (700–930 μg/L iAs in drinking water for decades) cohort residing in southwestern Taiwan was associated with carotid atherosclerosis indicated by cIMT (Wang et al., 2002). A relationship between arsenic and cIMT also has been observed in populations with lower exposures. Mateen et al. (2017) studied the association of baseline arsenic concentration in urine (sum of inorganic and methylated species) with several measures of atherosclerosis measured after follow-up among American Indians enrolled in the Strong Heart Study (SHS). Moon et al. (2013) described the concentrations of arsenic in drinking water for this cohort, which ranged from less than 10 to 61 μg/L. The mean difference in cIMT was 0.01 mm (95% CI: 0.00, 0.02 mm) comparing the 80th versus the 20th percentile of urine arsenic concentration. They also observed cIMT increases in exposure group quartiles 2 (5.65–9.24 μg/g creatinine), 3 (9.25–14.75 μg/g creatinine) and 4 (14.76–123.61 μg/g creatinine) of 0.01 (95% CI: −0.01, 0.02), 0.01 (95% CI: 0.00, 0.03) and 0.01 (95% CI: 0.00, 0.04), respectively. A borderline positive association with the presence of plaque was observed [RR: 1.04 (95% CI: 0.99, 1.09] also comparing the 80th versus the 20th percentile urine arsenic concentrations. Chen et al. (2013b) reported a 5.1-mm (95% CI: 0.2–10.3) increase in cIMT per standard deviation (SD) increase in baseline concentration of iAs in water (mean: 81.1 μg/L) and an 11.7-mm (95% CI: 1.8–21.6) increase in cIMT per SD increase in baseline urinary iAs concentration (mean: 259.5 μg/g) in the HEALS cohort. In this cohort, a sizeable proportion of the population is exposed to low or moderate arsenic in drinking water (median: 41 μg/L, 90th percentile 225 μg/L). The effect of arsenic exposure on cIMT thickness was greater among those with lower methylation capacity, indicated by arsenic metabolites in urine, and among smokers. Although associations were not exposure-dependent in a study by Chiou et al. (2001b), both water concentration and cumulative iAs exposure were associated with carotid atherosclerosis among the population of northeastern Taiwan, where the concentration in drinking water ranged from 0 to >3,000 μg/L. Atherosclerosis was associated with water arsenic concentrations (OR = 2.13, 95% CI: 1.04–4.32 comparing those with exposure ranging from 50– 99.9 μg/L to those in the reference category of <50 μg/L). Urinary arsenic concentration was associated with cIMT ≥1 mm in a cross-sectional analysis of participants in a study of residents in a farming village in South India where exposure to inorganic arsenic was generally from synthetic phosphate fertilizers [OR: 5.56 (95% CI: 2.42 to 12.7)] (Velmurugan et al., 2018). In a cross-sectional study done in Mexican children, the concentration of total arsenic in urine was associated with a 0.058-mm (95% CI: 0.0198–0.095) increase in cIMT among children in Mexico with >70 ng total arsenic/mL in urine. Drinking water concentrations of arsenic were reported to range between 3 and 135 μg/L at the time of the evaluation (see Figure 3-10) (Osorio-Yáñez et al., 2013). The association of arsenic exposure with cIMT was increased when methylation capacity (Huang et al., 2009) and activity of a paraoxonase gene, PON1, were low (Li et al., 2009). Modification of this association by genotypes of GSTM1, APOE, and HO-1 (Wu et al., 2010b; Hsieh et al., 2008b; Wang et al., 2007; Chiou et al., 2001b) and homocysteine level (Wu et al., 2006) was observed across these cohorts providing evidence that these factors may confer susceptibility to arsenic-associated cardiovascular effects.

Figure 3-13 Thumbnail schematic of case-control and cohort studies of atherosclerosis in response to inorganic arsenic exposure, ratio measures, drinking water, categorical exposure (see interactive data graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/DCS-atherosclerosis-ratiomeasure-case-contr/))

Figure 3-14 Thumbnail schematic of cross-sectional studies of atherosclerosis in response to inorganic arsenic exposure (a) ratio measures, urine, categorical exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/DCS-Atherosclerosis-cross-sectional-urine-cat-9df2/); (b) ratio measures, drinking water, categorical exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/DCS-Atherosclerosis-cross-sectional-drinking-f07d/) (see interactive data graphic)

(a) Ratio measures, urine, categorical exposure

(b) Ratio measures, drinking water, categorical exposure

###### Summary

Overall, these epidemiological studies indicate that low-to-moderate arsenic concentrations are associated with increased cIMT, supporting the associations of arsenic with atherosclerosis observed in other epidemiological studies. Effects on cIMT were greatest among those with lower methylation capacity indicated by metabolites in urine and among those with genes associated with lower methylation capacity or the regulation of atherosclerosis.

##### Electrocardiogram abnormalities

The literature review identified nine epidemiological studies, four case-control/cohort (Wang et al., 2010; Moon et al., 2018; Liao et al., 2009; Chen et al., 2013d) and five cross-sectional (Yildiz et al., 2008; Wang et al., 2009; Mumford et al., 2007; Mordukhovich et al., 2009; Feng et al., 2014), considered medium or high confidence that evaluated the association between iAs exposure and electrocardiogram abnormalities (see Figure 3-15 and Figure 3-16). These endpoints include repolarization abnormalities, such as QT prolongation, which reflect involvement of the autonomic nervous system and typically co-occur with hypertension. Long QT interval, or QT prolongation, is a repolarization abnormality associated with an increased risk of sudden death (Solti et al., 1989). QT prolongation is consistent with sympathetic hyperreactivity and often co-occurs with LVH and hypertension (Solti et al., 1989).

Figure 3-15 Study evaluation ratings for references evaluating electrocardiogram abnormalities (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Electrocardiogram-abnormalities/))

Figure 3-16 Thumbnail schematic of studies addressing the association electrocardiogram abnormalities and inorganic arsenic exposure, ratio measures, drinking water, categorical exposure (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/3f_DCS-Electrocardiogram-Abnormalities-OR/))

Moon et al. (2018) found associations of the sum of iAs and methylated arsenic in urine with ECG outcomes including QT interval (QTc) and JT interval (another marker of cardiac conduction) among American Indians in the SHS (urine arsenic median (IQR): 8.6 (5.2, 14.4) μg/g creatinine) and the Strong Heart Family Study (SHFS) (urine arsenic median(IQR): 4.3 (2.9, 7.1) μg/g creatinine. Participants had no heart disease or reported use of medications that could affect repolarization. In a cross-sectional analysis of older adult men enrolled in the U.S.-based Normative Aging Study, Mordukhovich et al. (2009) found that increasing toenail arsenic concentration (median (IQR): 0.069 (0.052, 0.11) μg/g) was associated with an increase in QTc. Arsenic exposure is presumed to be “low” in this cohort of residents of greater Boston, MA. Associations between arsenic exposure and QTc were also observed in cohorts where the highest arsenic concentrations in drinking water are typically higher than highest levels found in U.S. cohorts. Chen et al. (2013d) observed associations of both drinking water arsenic concentration (range: 0.1–790 μg/L) and urinary arsenic concentration (range: 7–4,306 μg/g creatinine) with heart rate corrected QTc among women, but not among men, in the HEALS cohort. Chronic arsenic exposure was associated with QTc prolongation in a small study of residents of Inner Mongolia exposed to arsenic concentrations in well water ranging from nondetectable (0.2 μg/L) to 690 μg/L (Mumford et al., 2007); The association was stronger in women than in men in this study, similar to the findings of (Chen et al., 2013d).

In addition to the studies examining repolarization parameters described above, a cross-sectional study of the association of heart rate variability with concentrations of various metals in urine conducted in Wuhan China reports a 19.8% (95% CI: 2.60, 33.96%) reduction in low frequency (LF) with a 10-fold increase in urinary arsenic concentration (geometric mean: 2.40 μg/mmol creatinine). Associations of urinary arsenic with other heart rate variability parameters were not significant and consequently not reported (Feng et al., 2014). Comparisons of those living in areas of Bangladesh where arsenic poisoning is endemic, to those living in other areas of these countries with relatively low concentrations of arsenic in drinking water also report correlations with QT prolongation and other repolarization parameters (Yildiz et al., 2008; Ahmad et al., 2006).

###### Highly exposed population: Southwestern Taiwan

Studies from the highly exposed cohort of southwestern Taiwan provide support for the effect of relatively high arsenic exposure on QT prolongation. These studies are addressed separately due to their limited relevance to U.S. populations, where the average drinking water concentrations are 500-fold lower, and the highest concentrations observed are still 10- to 100-fold lower. Wang et al. (2009) observed an association between cumulative arsenic exposure and QT prolongation. Higher cumulative exposures were associated with more pronounced QT prolongation decades after exposure had ended. In addition, clinical outcomes including IHD and carotid atherosclerosis (Wang et al., 2009) were associated with QTc prolongation in this cohort. In a follow-up study, Wang et al. (2010) examined the association of QT dispersion (QTD), considered an early biomarker of atherosclerosis, and cumulative arsenic exposure. An exposure-dependent association of cumulative arsenic exposure with QTD was observed. In addition, associations of QTD with IHD, carotid atherosclerosis, and cardiovascular-related mortality, were reported. In another, smaller study of this cohort, Liao et al. (2009) observed an association between arsenic exposure and electrocardiogram abnormalities; polymorphisms in two paraoxonase genes significantly increased the risks of ECG abnormality.

###### Summary

Overall, these studies provide consistent evidence of an association between QT prolongation and iAs exposure, thus supporting associations observed with CHD and hypertension in relation to arsenic. A dose-response gradient was observed in some studies [e.g., (Wang et al., 2009; Mumford et al., 2007; Liao et al., 2009)]. There is limited evidence that the association with QT prolongation may be stronger in women.

#### Cerebrovascular Disease and Stroke

The literature review identified 13 epidemiological studies, 9 case-control/cohort (Wade et al., 2009; Tsinovoi et al., 2018; Rahman et al., 2014; Moon et al., 2013; Merrill et al., 2017; Lewis et al., 1999; Farzan et al., 2015a; D’Ippoliti et al., 2015; Chen et al., 2011b) and crosssectional/ecological (Zierold et al., 2004; Xia et al., 2009; Lisabeth et al., 2010; Chiou et al., 1997) considered medium or high confidence that evaluated the association between iAs exposure and cerebrovascular disease and stroke (see Figure 3-17). In the HEALS cohort in Bangladesh, Chen et al. (2011b) reported weak to null associations of baseline concentrations of iAs in drinking water [HR: 1.07 (95% CI: 0.54, 2.12)]and urine [HR: 1.03 (0.53, 2.03)] with cerebrovascular disease-related mortality in models (see Figure 3-18). In another prospective cohort study conducted in Bangladesh, Rahman et al. (2014) found an exposure response for drinking water arsenic and stroke mortality across a range of exposures (0.5 to 3,644 μg/L), including those considered relevant to the U.S. Comparing those exposed to concentrations ≥50 μg/L to the reference group (<10 μg/L), the HR was 1.35 (95% CI: 1.04–1.75) (see Figure 3-18). Comparing those exposed to drinking water concentrations of 10–49 μg/L to the reference group, the HR was 1.20 (95% CI: 0.92–1.57). Stronger associations were reported for women than for men in this study.

Several additional studies add to the evidence base, including two analyses of the Reasons for Geographic and Racial Differences in Stroke (REGARDS) cohort, which is a study of adults (≥45 years old) who live in the continental U.S. (Merrill et al., 2017). Participants were assigned levels of arsenic derived from concentrations in environmental media (i.e., stream sediments and soils) recorded in the National Geologic Survey (NGS) database. An association between environmental arsenic concentration and incident stroke was observed [HR: 1.20 (95% CI: 0.98, 1.46) comparing the highest to the lowest quartile (6.42, 49.55 ppm) to (0.75, 2.15 ppm), respectively]. In the other REGARDS analysis Tsinovoi et al. (2018) examined the association of total urinary arsenic among a subcohort of n = 671 cases and n = 2,486 controls. Inorganic arsenic and arsenic metabolites were measured in a random sample of the subcohort (n = 199), with incident stroke (see Figure 3-18). No associations with total arsenic in the subcohort [HR: 1.01 (0.74–1.36) comparing the highest (≥20.55 μg/g creatinine) to the lowest quintile (<4.22 μg/g creatinine)] or with total inorganic arsenic among the random sample [HR 0.91 (0.64–1.30) per unit increase] were observed. A positive association with MMA was observed in the random sample of subjects with urinary metabolite measurements [HR: 1.98 (95% CI: 1.12– 3.50). No hazard ratio increase was observed by Farzan et al. (2015a) in their prospective analysis of the association between toenail arsenic and stroke-related mortality among participants in the New Hampshire Skin Cancer Study. However, when the Farzan et al. (2015a) cohort was evaluated across μg/g toenail exposure ranges (0.01–0.07, 0.07–0.11 and 0.11–3.26), relative risks for IHD- and stroke-related mortality were elevated in higher exposed groups over the lower reference group.

In the large study of Italian municipalities described previously, D’Ippoliti et al. (2015) reported positive associations of cumulative arsenic dose indicator, which accounted for lifetime intensity and duration of arsenic exposure given drinking water habits, with stroke in men (HR 1.74, 95% CI: 1.22–2.48) and women (1.82, 95% CI: 1.32–2.51). The results presented in parentheses compare the highest tertile index category (>804.0 μg/L) to the reference category (≤204.9 μg/L). Positive associations also were observed comparing the middle tertile to the reference category and also when exposure contrasts were determined based on average water concentration (10–20 μg/L and >20 μg/L) (see Figure 3-18).

Several additional studies assessed the association of iAs exposure with stroke or cerebrovascular outcomes (see Figure 3-19). Chiou et al. (1997) reported a positive association between iAs concentration in drinking water and the prevalence of cerebrovascular disease and cerebral infarction in northeastern Taiwan (range of arsenic in well water: <0.1– ≥300 μg/L). Inverse or null associations of arsenic with stroke prevalence or stroke-related mortality, however, have also been reported in studies of Inner Mongolia, China (Wade et al., 2009; Xia et al., 2009) and Utah, U.S. (Lewis et al., 1999).

Figure 3-17 Study evaluation ratings for references evaluating cerebrovascular disease and stroke (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Cerebrovascular-disease-and-stroke/))

Figure 3-18 Thumbnail schematic of case-control and cohort studies of cerebrovascular disease and stroke in response to inorganic arsenic exposure, (a) ratio measures, drinking water, categorical exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/3h_1DCS-Stroke-OR-or-similar-logscale_ILD/); (b) ratio measures, biomarkers, categorical exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/DCS-Cerebrovascular-ratio-measures-case-contr-27ef/) (see interactive data graphic)

(a) Ratio measures, drinking water, categorical exposure

(b) Ratio measures, biomarkers, categorical exposure

Figure 3-19 Thumbnail schematic of cross-sectional studies of cerebrovascular disease and stroke in response to inorganic arsenic exposure, ratio measures, drinking water, categorical exposure (see interactive data graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/3h_2DCS-Stroke-OR-or-similar-logscale_ILD/))

##### Supplemental information: Meta-analysis

In the meta-analysis by Moon et al. (2012) relatively weak (compared with CHD) and imprecise pooled estimates for stroke were reported. To obtain the pooled estimates for high-exposure areas and areas with low-to-moderate exposure, the authors stratified the studies by mean iAs concentration greater than 50 μg/L or less than 50 μg/L and compared the risk in the highest exposure group in each study to the risk in the lowest exposure group. The pooled estimates obtained were 1.08 (95% CI: 0.98–1.19) in high-exposure areas, and 1.07 (95% CI: 0.96, 1.20) in low to moderate exposure areas.

##### Summary

Findings from the epidemiological studies are limited with some uncertainty. Overall, epidemiological studies provide primarily consistent evidence of an association between arsenic exposure and cerebrovascular disease and stroke and mortality from cerebrovascular causes. A dose-response gradient was observed in many (Rahman et al., 2014; Moon et al., 2013; Merrill et al., 2017; D’Ippoliti et al., 2015; Chiou et al., 1997; Chen et al., 2011b) but not all studies. The gradient was consistently observed in populations with higher (>100 μg/L) concentrations of iAs in drinking water, but some inconsistencies were observed across study findings.

#### Other Vascular Diseases

The literature review identified seven epidemiological studies, five case-control/cohort (Tseng et al., 2005; Pi et al., 2005; Hsieh et al., 2008a; D’Ippoliti et al., 2015; Chiou et al., 2005) and two cross-sectional (Tseng et al., 1996; Tseng et al., 1997), considered medium or high confidence that evaluated the association between iAs exposure and other vascular disease (see Figure 3-20). Blackfoot disease, a peripheral vascular disease (PVD) characterized by gangrene in the extremities, is well documented in the southwestern coastal region of Taiwan, where the population was exposed to high concentrations of iAs (700–930 μg/L) in drinking water for several decades (Tseng, 2002). Arsenic exposure also is associated with microvascular diseases, including those affecting the nervous and renal systems in this population. Erectile dysfunction (Hsieh et al., 2008a) and PVD (Tseng et al., 1996; Tseng et al., 2005) are reported in this southwestern Taiwan region. Tseng et al. (2005) found that those with a lower capacity to methylate arsenic had a higher risk of PVD. In a prospective analysis of several Italian municipalities, HRs for mortality from PVD were increased but confidence intervals were wide for both males and females (study participants were followed from 1990 to 2010 and exposed, on average, to 19.3 μg/L for 39.5 years) (D’Ippoliti et al., 2015). In a study conducted in China, Pi et al. (2005) reported a reduction in response to cold stress, a symptom of PVD, after an intervention to reduce exposure to arsenic in drinking water among patients with chronic arsenic poisoning. Chiou et al. (2005) used arsenic levels in well water as indices of previous ingestion levels, finding an association between drinking water arsenic concentration and microvascular disease prevalence in the cohort. These few studies of vascular endpoints provide consistent evidence for an array of effects of arsenic on the vascular system at high concentrations.

Figure 3-20 Study evaluation ratings for references evaluating other vascular diseases (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Other-vascular-diseases/))

#### Circulatory Markers of Cardiovascular Risk

Circulating blood or serum markers of CVD risk were examined in 10 epidemiological studies, three cohort (Moon et al., 2017a; Kuo et al., 2018; Das et al., 2012) and seven cross-sectional (Wu et al., 2012b; Osorio-Yáñez et al., 2013; Mendez et al., 2016; Karim et al., 2013; Chen et al., 2007; Chen et al., 2012b; Burgess et al., 2013) (see Figure 3-21). Moon et al. (2017a) examined the association of iAs in urine (median (IQR): 8.4 (5.1, 14.3) μg/g creatinine) with plasma fibrinogen, PAI-1, and CRP among American Indians participants of the Strong Heart Study (SHS). A positive association with plasma fibrinogen was found among those with diabetes. These biomarkers were not associated with iAs exposure among those without diabetes. Low levels of iAs in drinking water (mean 7.65 μg/L) were associated with serum matrix metalloproteinase-9 in residents of Arizona and Mexico (Burgess et al., 2013). The association of asymmetric dimethylarginine with cIMT in arsenic-exposed children (drinking water arsenic concentration range: 3–135 μg/L) in Mexico provides another potential biomarker of interest (Osorio-Yáñez et al., 2013).

A study of the HEALS cohort in Bangladesh reported cross-sectional associations of baseline well water arsenic concentration (range: 0.10–500.62 μg/L) with markers of endothelial dysfunction and vascular inflammation (Wu et al., 2012b). Chen et al. (2007) found a significant association with endothelial adhesion molecules, which have been associated with endothelial dysfunction, in this cohort (range: 0.1–864.0 μg/L). Karim et al. (2013) reported correlations between arsenic concentrations in water, hair, and nails with markers of inflammation and coagulation, including C-reactive peptide and oxidized low-density lipoprotein as well as with markers of endothelial dysfunction among participants in another study in rural Bangladesh. Das et al. (2012) reported a significant increase in inflammatory cytokine levels associated with cardiovascular disease (IL6 and IL8) in arsenic-exposed (mean (SD): 202.68 (188.12) μg/L) vs. unexposed (mean (SD): 5.38 (2.06) μg/L) individuals in West Bengal, India. Taken together the evidence indicates that there is a correlation between inorganic arsenic exposure and increased markers for circulatory risk.

Figure 3-21 Study evaluation outcomes for references evaluating circulatory markers for CVD risk (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Markers-for-CVD-risk/))

##### Highly exposed population: Southwest Taiwan

Lipid abnormalities are an established risk factor for CVD. Lipid profiles did not differ between cases and non-cases of PVD in the highly exposed population of southwestern Taiwan (Tseng et al., 1997), but this observation might reflect the inadequacy of measuring lipid profiles several years after arsenic exposure. An association was reported between cumulative arsenic exposure (ppm-years) and abnormal lactate dehydrogenase activity, a marker of CVD risk, in this cohort (Liao et al., 2012).

#### Mechanistic Observations and Biological Plausibility

As summarized above there is strong evidence from prospective cohort and case control studies showing an association between iAs exposure and ischemic heart disease (IHD) related outcomes, including IHD incidence and mortality. There is also consistent evidence from case control, cohort, and cross-sectional studies reporting generally consistent exposure dependent associations between arsenic and atherosclerosis. The mechanistic literature database includes numerous in vivo and in vitro studies evaluating these factors with a majority of the experimental data focusing on oxidative stress, angiogenesis, atherosclerotic plaque formation, and effects on vascular tissue (for more information see Appendix A of the iAs protocol). Below we discuss the mechanistic evidence for each of these mechanisms and their implications on IHD and atherosclerosis. Atherosclerosis is a disease of the arterial wall which involves thickening and loss of elasticity of the walls of the arteries that occurs with formation of atherosclerotic plaques within the arterial intima, the inner layer of the arteries lined by a mono layer of endothelial cells which are in direct contact with blood. Atherosclerotic plaques are composed of cholesterol, fatty substances, cellular waste products, calcium, and fibrin. Build-up of these plaques can occlude blood flow of oxygen rich blood and lead to myocardial infarctions, stroke, and death It is widely accepted that atherosclerosis is a process that involves a chronic inflammatory state, which leads to endothelial cell activation, dysfunction and accumulation of lipids, recruitment of leukocytes, proliferation of smooth muscle cells within the arterial wall, development of foam cells and eventually, deposition of extracellular matrix (Ross, 1999; Libby et al., 2011). It should be noted that the development and progression of atherosclerosis is a dynamic and multistep process that occurs over the course of multiple years. However, the progression of the disease can still be grouped into three distinct stages: (i) early changes (ii) plaque formation and ultimately (iii) plaque disruption (Ross, 1999; Libby et al., 2011).

##### Stage 1: Early changes

As noted previously the development of atherosclerosis is a complex multistage process, a combination of two principal hypotheses that are widely accepted in the field. These include the stress of intimal cellular proliferation and the recurrence of thrombi which over time organize into clinically significant plaques (Sidhu et al., 2015; Ross, 1999). The increase in reactive oxygen species (ROS) has been widely documented as an initiating event in the progression of the disease. Increases in ROS are normally tempered by antioxidant enzymes such as gluthatione S transferase and superoxide dismutase. When these antioxidant defenses are exhausted there is an increase in oxidative stress that can contribute to the depletion of tetrahydrobiopten (BH4), an essential cofactor in the synthesis of nitric oxide synthase. Depletion of BH4 further contributes to oxidative stress. Additionally, oxidative stress leads to the activation of inflammatory cytokines, such as VCAM and ICAM, and systemic inflammation. Systemic inflammation leads to endothelial cell activation. Endothelial cell activation is typically a normal response to tissue injury or infection by endothelial cells in post-capillary venules to release chemokines that attract white blood cells (WBCs) to the area and concomitantly produce cell surface adhesion molecules that enables anchoring of leukocytes to the endothelial surface and transmigration to the site of injury. A pathologic version of this process during atherosclerotic plaque formation. Prolonged oxidative stress and or inflammatory states can alter the ability of endothelial cells to maintain homeostasis, this is known as endothelial cell dysfunction. Endothelial cell dysfunction leads to the development of pathological inflammatory processes, such as vascular disease and has been associated with metabolic disorders such as insulin resistance and type 2 diabetes (Esper et al., 2006).

##### Stage 2: Plaque formation

Fatty streaks, atheromas and foam cell aggregates begin development after endothelial cell dysfunction occurs. Formation and progression of atherosclerotic plaques are largely driven by the migration of smooth muscle cells (SMCs) into the tunica intima as well as by the subsequent proliferation of SMCs post-migration (Sidhu et al., 2015; Libby et al., 2011). Overtime contribution from proinflammatory cytokines and growth factors such as PDGF, FGF, and TNF-alpha contribute to the formation of fatty streaks that further stimulate SMC migration and proliferation. This generates a cycle that maintains and further stimulates detrimental inflammation at the site of the developing plaque. Ultimately SMC migration leads to collagen synthesis and the genesis of an extracellular matrix component that functions to stabilize and forms a fibrous plaque.

##### Stage 3 Plaque disruption

The stability of the fibrous cap depends largely on the balance between ECM deposition and degradation. A fibrous cap may protrude into the arterial lumen and occlude arterial blood flow. Alternatively, plaques that contain less collagen are more likely to rupture and lead to adverse clinical outcomes such as myocardial infarction and stroke.

Inorganic arsenic exposure has been associated with increased risk of cardiovascular disease in both humans (Wade et al., 2015; Sohel et al., 2009; Moon et al., 2013; Chen et al., 2011b) and experimental animals (Srivastava et al., 2007; States et al., 2009 (https://hero.epa.gov/hero/index.cfm/reference/details/reference_id/628058); Lemaire et al., 2011). It was shown by Wu et al. (2010b) that there was an increase in atherosclerotic risk in Taiwanese individuals containing polymorphisms in GST gene. Additionally, it has been shown that the metabolism of arsenic, widely thought to have been a detoxifying mechanism, produces homocysteines as arsenic is methylated from arsenic to MMA to DMA. Elevated plasma homocysteine levels have been shown to be a reliable bioindicator of increased atherosclerotic risk and have been shown to contribute to ER stress, endothelial cell activation, inflammation, and cell proliferation (Papatheodorou and Weiss, 2007). Additionally, inorganic arsenic has been shown to lead to reactive oxygen species production and oxidative stress (see Appendix A of the iAs protocol). As discussed previously prolonged oxidative stress leads to endothelial cell dysfunction, foam cell formation and overtime the progression of atherosclerosis.

##### Oxidative Stress

The increase in reactive oxygen species (ROS) has been widely documented as an initiating event in the progression of arsenic induced diseases, including atherosclerosis [see Appendix A of the iAs protocol and (Lind et al., 2021)]. Arsenic induces the formation of reactive oxygen species (ROS) such as O_2_^•-^, H_2_O_2_, and OH^•^, through direct and indirect mechanisms throughout the system. Increases in ROS are normally tempered by antioxidant enzymes such as glutathione peroxidase, glutathione S transferase and superoxide dismutase (Handy and Loscalzo, 2022). However, when these antioxidant defenses are exhausted there is an increase in oxidative stress that can contribute to the depletion of tetrahydrobiopterin (BH4), an essential cofactor in the synthesis of nitric oxide synthase (NOS) (Wu et al., 2021). NOS is an enzyme that produces nitric oxide (NO), a signaling molecule that plays many roles in the cardiovascular system (Wu et al., 2021; Roy et al., 2023; Förstermann and Sessa, 2012; Carnicer et al., 2013) including regulation of myocardial function (Carnicer et al., 2013), inhibition of platelet aggregation and adhesion (Förstermann and Sessa, 2012), regulation of vascular smooth muscle proliferation (Roy et al., 2023; Förstermann and Sessa, 2012; Carnicer et al., 2013) and stimulation of angiogenesis (Roy et al., 2023; Förstermann and Sessa, 2012; Carnicer et al., 2013). Depletion of BH4 further contributes to oxidative stress. Increases in ROS production in endothelial cells, results in endothelial inflammation (Bunderson et al., 2004; Barchowsky et al., 1996; Barchowsky et al., 1999) and increases in the expression of intercellular adhesion molecule 1 (ICAM-1) and vascular cell adhesion molecule 1(VCAM 1). ICAM-1 and VCAM-1 are adhesion molecules expressed on the surface of endothelial cells that play a crucial role in the development of atherosclerotic plaques by facilitating the adhesion and migration of leukocytes to the arterial wall and subsequent plaque formation (Singh et al., 2023). Arsenic exposure (in vitro in rodent primary aorta endothelial and smooth muscle cells or in human lymphocytes) and subsequent ROS production induces ICAM-1 and VCAM-1 (Singh et al., 2023) as well as several genes associated with cellular inflammation, including interleukin-8, interleukin-1 beta, interleukin-6, and chemokine C-C motif ligand 2/monocyte chemotactic protein-1 (Simeonova et al., 2003; Wu et al., 2003).

ROS are also key mediators of vascular leakage, and loss of ROS homeostasis can contribute to vascular disease (Veeraraghavan et al., 2020; Chen et al., 2017). High levels of ROS in the system can cause vascular damage and vascular leakage. As an example, high levels of ROS can activate cell signaling pathways that lead to phosphorylation of VE-cadherin, a protein that plays a critical role in the maintenance of blood and lymphatic vessels, resulting in compromised adherens junctions (Veeraraghavan et al., 2020; Chen et al., 2017). High levels of ROS can also activate endothelial cells, which can lead to vascular leakage (Veeraraghavan et al., 2020; Chen et al., 2017). Lastly ROS can also lead to vascular remodeling by promoting vascular cell growth, inflammation, and deposition of extracellular matrix (Lind et al., 2021; Chen et al., 2017). Arsenic-induced vascular leakage has been proposed to be instrumental in induction of CVD. Chen et al. (2008) reported increased vascular permeability in the skin of rats after intradermal injections of arsenic. The increased permeability resulted from increased production of ROS, specifically: nitric oxide, hydroxyl radical, and peroxynitrite. In an in vitro study in mouse brain endothelial cells, Bao et al. (2010) reported increased vascular permeability after treatment with 5-μM arsenic. The vascular permeability was mediated by ROS resulting from arsenic exposure, causing the release of vascular endothelial growth factor (VEGF). Arsenic stimulates the expression of VEGF partially by inducing the heme oxygenase-1 (HO1) system, through the inactivation of the transcription factor Bach 1, which allows Nrf2 (nuclear factor erythroid-derived 2 related factor-2) to bind to the HO-1 promoter and cause HO-1 induction (Meng et al., 2010). Arsenic has also been found to cause dysfunction in blood vessel relaxation and to cause vascular constriction (Lee et al., 2003).

##### Angiogenesis

Arsenic exposure has been linked with dysregulation of angiogenesis, the formation of new blood vessels from existing vessels in adult tissue (Liu et al., 2011). Dysregulation of angiogenesis has been observed in several cardiovascular diseases including atherosclerosis and ischemic heart disease (Loomans et al., 2004; Kao et al., 2003; Hayden and Tyagi, 2004; ATSDR, 1996).

##### Evidence in humans

In a cross-sectional study, (Osorio-Yáñez et al., 2013) investigated the association between iAs exposure, carotid intima thickness (cIMT), plasma asymmetric dimethylarginine (ADMA), and endothelial adhesion molecules in a pediatric population exposed to 3-135 ng/mL from Zimapan, Mexico. ADMA is a metabolic byproduct of protein modification processes and has been shown to inhibit nitric oxide (NO) synthesis resulting in decreases endothelial cell function. Increases in ADMA levels have been used to predict subsequent cardiovascular disease (Leong et al., 2008). The authors reported that increases in total arsenic (tAs) were associated with increased carotid intima thickness (cIMT) and increased ADMA. The authors also reported that plasma soluble vascular cell adhesion molecules (sVAM-1) along with cIMT, and percent tAs were significant predictors of ADMA levels (0.419 μmol/L increase in ADMA per 1 mm increase in cIMT). The reported increases in ADMA, sVAM-1, and cIMT were present in the absence of increases in serum lipids (Osorio-Yáñez et al., 2013), consistent with observations in other arsenic exposed human populations and in experimental animals (Simeonova et al., 2003; Hsueh et al., 1998).

##### Evidence in animals

Soucy et al. (2003) observed that C57BL/6 mice injected i.p. with 0.8, 8, or 80 μg/kg-day of sodium arsenite (NaAsO_2_; equivalent to 0.8- 80 ppm) daily for three weeks had an increase in angiogenesis as measured by Matrigel mouse model. The authors found that FGF-2^16^ (50 ng/mL) had a biphasic effect on blood vessel density when combined with low (0.8 μg/kg-day) and high (80 μg/kg-day) doses of iAs. Blood vessel density increased at these outermost iAs doses but remained unchanged at the intermediate dose. The authors only included luminal vessels containing fixed red blood cells in their quantification of vessels however, because not all capillaries contain red blood cells as some capillaries may be in a resting state or only partially perfused, meaning that they may not have had red blood cells at the time of observation. Also red blood cell distribution can be uneven (e.g., in areas with slower blood flow or in smaller vessels) and by including only luminal vessels containing red blood cells the authors could have missed capillaries and underestimated the total number of capillaries. By only considering vessels with fixed red blood cells, Soucy et al. (2003), may have missed a significant portion of the capillary network, resulting in a potential bias of the affect and interpretation of the study findings and conclusions. In a follow up study, Soucy et al. (2005) showed that C57BL/6NCr mice exposed to low-level arsenic exposure (0 to 50 ppb in drinking water) for five weeks formed enhanced neovascularization, the process of new blood vessels formation, in Matrigel at arsenic concentrations as low as 5 ppb (p <0.05). Enhanced neovascularization by arsenic could contribute to dysregulation of angiogenesis and contribute to the growth of atherosclerotic lesions and plaque formation (Khurana et al., 2005 (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=3337248)).

The study also showed that exposure of C57BL/6NCr mice to arsenic at higher doses for a greater duration (50-500 ppb iAs for five, ten, or twenty weeks) showed increased neovascularization. Significant dose dependent increases in neovascularization were observed at 5 weeks (50 ppb p <0.05; 250 ppb p <0.01; and 500 p <0.001). Significant increases in neovascularization were also observed at 10 weeks at all three exposure levels (50, 250, and 500 ppb iAs; p < 0.05). However, at 20 weeks, significant neovascularization was only observed in mice exposed to 50 and 250 ppb iAs in drinking water. No increased in neovascularization was observed at the 500 ppb iAs exposure level.

In damaged endothelium, VEGF, endothelin-1, and matrix metalloproteinases (MMPs) are induced in endothelial cells to facilitate angiogenesis. To probe the underlying mechanisms of the observed neovascularization, Soucy et al. (2005) showed that chronic arsenic exposure differentially affected angiogenic and remodeling gene expression. Early in the process (five weeks) arsenic increased the expression of VEGF, VEGF receptor 1 (VEGFR1), and PAI-1 in mice exposed to 250 and 500 ppb iAs. VEGF receptor 2 (VEGFR2) and MMP-9 expression increased at twenty weeks in the mice exposed to 50, 250, and 500 ppb iAs. Lastly, Endothelin-1 expression was increased in mice exposed to 50 and 250 ppb iAs for twenty weeks. These results indicate that the underlying mechanism(s) involved in arsenic-stimulated angiogenesis may differ depending on iAs concentration and duration of exposure (Soucy et al., 2005).

Using liver as a model for studying the mechanisms by which inorganic arsenic affects vascularization and angiogenesis, Straub et al. (2008) showed that arsenic stimulated liver sinusoidal capillarization in mice was dependent on NAPDPH-oxidase generation of superoxide. Utilizing wildtype C57BL/6 mice, Straub et al. (2008) showed a significant dose-dependent decrease in porosity (described as percent open space in liver fenestrations relative to the area of vessel wall) and a dose-dependent increase in PECAM-1 expression in mice exposed to 0,10, 50, 100, or 250 ppb sodium arsenite in drinking water for two weeks (p< 0.01). Primary SECs exposed to 0, 1, 2.5, or 5 μM iAs for eight hours repeated the same pattern observed in vivo. Straub et al. (2008) also used p47^PHOX^ knockout mice to study the effects of arsenic on vascularization and angiogenesis. p47 is a canonical essential cytosolic subunit of NOX-2-oxidase, p47^PHOX^ knockout mice are unable to produce superoxide and have been used to study the role of p47phox in vascular dysfunction (Rezende et al., 2018; Chen and Stinnett, 2008). Straub et al. (2008) exposed p47^PHOX^ knockout mice to 100 ppb in drinking water for two weeks did not have the decrease in porosity of the liver observed their wildtype counterparts. The attenuation of liver porosity in the p47^PHOX^ knockout mice demonstrated that NADPH oxidase was required for arsenic- stimulated capillarization in vivo. These results were coherent or consistent in primary SECs derived from p47^PHOX^ knockout animals exposed to 2.5 mM iAs (324.8 ppm) or 50 mM H_2_O_2_, for eight hours, where H_2_O_2_ but not iAs, decreased porosity in p47 null primary SECs. In addition, arsenic failed to increase nitrosylation in p47 null mice suggesting that superoxide (SO) generation and peroxynitrite formation are primary mechanisms involved in vasculature remodeling of the liver and impaired sinusoidal function observed in response to arsenic exposure (Straub et al., 2008).

Humanized rodent models such as apolipoprotein E knockout (ApoE-/-) mice have also been used to study the cardiometabolic effects of arsenic (Srivastava et al., 2009; Simeonova et al., 2003; Makhani et al., 2018; Lemaire et al., 2011). ApoE (-/-) mice are apolipoprotein E deficient and display poor lipoprotein clearance with subsequent accumulation of cholesterol ester-enriched particles in blood. The accumulation of these particles promotes the development of atherosclerotic plaques. The ApoE -/- mouse model has been well established for the study of human atherosclerosis as it emulates human lipid profiles and the anatomical localization and histopathological characteristics of the plaques that are produced in this mouse model more closely resemble human atherosclerosis as compared to other mouse models (eg., high-fat diet-induced mouse model (wild-type)). Simeonova et al. (2003) exposed female wild-type C57BL/6 and female ApoE -/- mice to 0, 20, or 100 ug/mL (0, 20 or 100 ppm) sodium arsenite in drinking water for 24 weeks. Transgenic animals exposed to sodium arsenite showed a dose dependent increase in atherosclerotic lesions covering the intimal area of the aorta versus nontreated transgenic mice (p <0.02) and Wildtype C57BL/6 animals exposed (treated and control). Further, the As-mediated increases in atherosclerotic plaques were not accompanied with increased serum cholesterol, similar to observations of atherosclerosis in arsenic exposed, human populations (Hsueh et al., 1998). However, it was observed that atherosclerotic plaque progression was associated with the accumulation of arsenic in the cardiovascular tissue in the ApoE ^-/-^ mice (Simeonova et al., 2003), indicating a direct association with arsenic exposure. In a similar study, Lemaire et al. (2011) exposed male ApoE -/- mice to a much lower concentration of sodium arsenite (200 ppb for 13 weeks) and observed that the mice developed atherosclerotic lesions. The authors also reported that arsenic altered the plaque content; arsenic-induced plaques had decreased smooth muscle cells and collagen within the plaque making these plaques less stable, more susceptible to rupture and at increased risk of producing a myocardial infarct or stroke in humans. Additionally, the arsenic-induced plaques contained increased lipid content without increases in macrophages. In a follow up study, Makhani et al. (2018) exposed male ApoE -/- male mice to sodium arsenite in drinking water at doses ranging from 10 to 200 ppb (0, 10, 50, 100 or 200 ppb) for 13 weeks and observed a dose dependent increase in the size of the atherosclerotic plaques within the aortic sinus with significant differences from control mice starting at the lowest arsenic concentration tested (p < 0.05 at 10 ppb). The authors also analyzed the plaque content and observed that the components of the arsenic induced plaques had increased macrophage lipid accumulation, suggesting that macrophage-lipid homeostasis is sensitive to perturbation by arsenic (Makhani et al., 2018). In addition, the authors observed that arsenic-induced plaques had deceased smooth muscle cells and collagen content, making these plaques more susceptible to rupture and increasing risk for infarction and stroke, however these effects only reached statistical significance at the higher concentrations of arsenic exposure tested (100- 200 ppb).

##### Evidence from in vitro models

Straub et al. (2008) built on the work of Smith et al. (2001) and Lynn et al. (2000) showing that arsenic stimulates Nox-based oxidase activity through mobilization and activation of Rac-1-GTPase and increases Rac-1 association with sinusoidal endothelial cells (SEC) membranes during capillarization. In this study, Straub et al. (2008) showed that inhibition of Rac-1 GTPase provided protection from arsenic stimulated defenestration in SECs.

Hays et al. (2008) investigated early events in arsenic-induced vascular pathology. C57BL/6 male mice were exposed to 0 or 50 ppb sodium arsenic in drinking water for four, five, or eight weeks. The lungs from the experimental animals were excised and gene expression changes were measured using Affymetrix mouse array. The authors did not report any statistical significance in gene expression in any of the animals exposed to arsenic compared to control (Hays et al., 2008).

#### Risk Modifiers

A review of the epidemiological studies discussed in this section, along with studies identified from a targeted literature search on modifying factors (see Section 3.10 of iAs Protocol) identified in Table 3-2, suggest that the following factors increase the risk of arsenic-associated cardiovascular effects:

- Methylation capacity: Individuals who metabolize iAs to MMA and DMA less efficiently have an increased risk of arsenic-induced cardiovascular disease. This is based on findings—from multiple studies across a wide range of populations—that derive indicators of methylation capacity from the concentrations of arsenic metabolites found in urine. These studies indicate that lower methylation capacity increases the risk of arsenic-associated cardiovascular effects including IHD and hypertension. Supporting evidence is provided by studies reporting that the risk of arsenic-associated cardiovascular outcomes is modified by polymorphisms linked to methylation capacity. A case-cohort analysis of a large Bangladesh population studied by Chen et al. (2011b) reported increased risk of IHD-related mortality among those with lower methylation capacity, suggesting that low methylation capacity may increase the risk of arsenic-associated mortality (Chen et al., 2013c)
- Smoking: Smoking increases the risk of arsenic-associated cardiovascular effects and smokers are a susceptible population. Two prospective cohort studies of iAs and CHD-related mortality reported effect modification by smoking status. An interaction was detected between iAs concentration in drinking water and current smoking in the HEALS cohort of Bangladesh (Chen et al., 2011b). In this study, the relative excess risk for interaction comparing ever to never smokers were 1.56 (95% CI: 0.05–3.14). In a longitudinal analysis of data from the New Hampshire Skin Cancer Study, a population-based cohort study, Farzan et al. (2015a) reported an association of CVD with toenail arsenic in current smokers (HR = 1.69, 95% CI: 1.04–2.75) but not in never smokers (HR = 0.84, 95% CI: 0.58–1.21). Similar results were obtained when smoking status was defined as years of smoking or pack-years. In addition, the association observed between arsenic exposure and cIMT thickness was greater among smokers (Chen et al., 2013b).
- Genetic variation: Although the evidence is limited, several studies suggest that genes related to the regulation of atherosclerosis might increase the risk of arsenic-associated cardiovascular effects. Several epidemiological studies (see Table 3-2) examined the interaction between arsenic exposure and various polymorphisms that increased the risk of cardiovascular endpoints, including electrocardiogram abnormality, carotid atherosclerosis, coronary heart disease, cIMT, and hypertension. Genetic variants may also alter the metabolism of inorganic arsenic independently of excretion or absorption (e.g., glutathione S-transferase (GST), arsenic 3+ methyl transferase (AS3MT)) leading to increased susceptibility.
- Life stages: Although the evidence is limited, several studies suggest that early life represents a susceptible lifestage for arsenic exposure and subsequent myocardial infarction. Studies (see Table 3-2) have also reported increased blood pressure and cIMT among children exposed to arsenic during early life (in utero and during early childhood).
- Nutrition: Although the evidence is limited, several studies suggest that those with nutrient deficiencies are a susceptible population with respect to arsenic exposure and subsequent hypertension. One study indicates that hypertension is associated with iAs only among those deficient in vitamin B and folate.
- Sex: Overall, neither males nor females clearly represent a susceptible population. Several studies have evaluated sex as a modifier of the association between arsenic exposure and various cardiovascular outcomes. Although risk estimates sometimes differed in males compared with females in some studies, no overall pattern emerges suggesting that either sex is more susceptible to the effects of arsenic exposure on CVD and related outcomes.

Table 3-2 Risk modifiers for cardiovascular disease from targeted search

Modifying factor | Key reference | Effect | Population, exposure level
Methylation capacity | Wu et al. (2006) | Increased risk of carotid atherosclerosis (OR = 2.7, 95% CI: 1.0–7.8) in residents with arsenic exposure >100 μg/L with plasma homocysteine levels ≥12.7 μmol/L and monomethylarsonic acid (MMA) ≥16.5% compared with those with plasma homocysteine levels <12.7 μmol/L and MMA <16.5% (OR = 1.7, 95% CI: 0.6–5.2) | Taiwan, <50–>100 μg/L (water)
| Tseng et al. (2005) | Increased risk of peripheral vascular disease in residents with cumulative arsenic exposure >100 μg/L-yr and for PMI >1.77 and SMI >6.93 ( OR = 2.93 95% CI: 0.90–9.52), PMI >1.77 and SMI ≤6.93 ( OR = 2.85, 95% CI: 1.05–7.73), PMI ≤0.77 and SMI ≤6.93 ( OR = 3.60, 95% CI: 1.12–11.56) | Taiwan, 700–930 μg/L (median water)
| Wang et al. (2011) | Significant association reported between lower methylation capacity (indicated by higher urinary concentrations of arsenate) and increased risk of hypertension; potential synergistic effect also observed between lower methylation capacity and higher BMI, and increased odds of hypertension | Taiwan, 700–930 μg/L (median water)
| Chen et al. (2013b) | Positive association between arsenic exposure and increase in carotid intima-media thickness and for every 10% increase in urinary MMA, 12.1-μm increase (95% CI: 0.4–23.8) in carotid intima-media thickness | Bangladesh, 81.1 μg/L (mean water)
| Li et al. (2013a) | Significant negative relationship between hypertension and % DMA (adjusted OR = 0.036, 95% CI: 0.002–0.822) for arsenic exposure >50 μg/L | China, <10–>50 μg/L (water)
| Li et al. (2013b) | Residents with higher MMA levels had significantly increased risk for hypertension (OR = 1.693, 95% CI: 1.028–2.787) compared with those with lower MMA levels, and those with higher DMA levels had decreased risk of hypertension (OR = 1.549, 95% CI: 0.938–2.559) compared with those with lower levels of DMA | China, 0–650 μg/L
| Li et al. (2015) | Significantly higher odds of hypertension among individuals with low methylation capacity (indicated by lower DMA% and SMI) compared with subjects with indicators of higher methylation capacity; potential synergistic effects also observed between lower methylation capacity and older age, higher BMI, and smoking, and increased odds of hypertension | China, <0–760 μg/L range (water)
| Farzan et al. (2015b) | Associations were reported between urinary arsenic and blood pressure among both those with higher PMI or higher SMI | United States, 0.35 to 288.5 μg/L range (water)
Smoking | Chen et al. (2011b) | Significant synergistic effect between arsenic exposure and smoking and increased mortality from ischemic heart disease and other heart disease | Bangladesh, <12–>148 μg/L (water)
| Tseng et al. (2005) | No increased risk from smoking for peripheral vascular disease associated with arsenic exposure | Taiwan, 700–930 μg/L (median water)
| Farzan et al. (2015a) | Significantly increased risk of mortality due to ischemic disease among current smokers compared with never smokers, and those reporting ≥31 yr or ≥30 pack-yr of smoking, respectively, compared with 0 pack-yr of smoking | United States, 0–158.1 μg/L range (water)
Genetic Variation | Liao et al. (2009) | Polymorphisms in two paraoxonase genes (PON1 and PON2) and cumulative arsenic exposure >14,700 μg/L-yr associated with increased risk of electrocardiogram abnormality | Taiwan, 350–1,140 μg/L (water, 1960s)
| Li et al. (2009) | No significant association between atherosclerosis and cumulative arsenic exposure >15,000 μg/L-yr with four polymorphisms of the PON genes (PON1-108C/T, PON1 Q192R, PON2 A148G, PON2 C311S) | Taiwan, <100–>15,000 μg/L (water)
| Hsieh et al. (2008b) | Increased risk of carotid atherosclerosis with arsenic exposure >10 μg/L and polymorphisms in apolipoprotein E (APOE) (epsilon 4 allele) and monocyte chemoattractant protein-1 (MCP-1) (A/G or G/G) | Taiwan, <10–>50 μg/L (water)
| Chiou et al. (2001b) | Increased risk of carotid atherosclerosis with arsenic exposure >50 μg/L and polymorphisms of glutathione S-transferase (GSTM1, GSTT1, and GSTP1) | Taiwan, <0.15–3,590 μg/L (water)
| Wang et al. (2007) | Increased risk of carotid atherosclerosis with arsenic exposure >50 μg/L and GSTP variant (lle/Val and Val/Val) and p53 variant (Arg Pro and Pro/Pro) genotypes | Taiwan, <10–>50 μg/L (water)
| Wu et al. (2010b) | Absence of class S allele of heme oxygenase-1 (HO1) gene with arsenic exposure >750 μg/L associated with increased risk of carotid atherosclerosis | Taiwan, <10–>750 μg/L (water)
| Wu et al. (2010a) | Significantly reduced risk of coronary heart disease, cerebrovascular disease, and peripheral arterial disease with arsenic exposure <150 μg/L for carriers of the L/S or S/S genotypes of the HO-1 gene compared with noncarriers | Taiwan, <50–>300 μg/L (water)
| Wu et al. (2011) | Reduced risk of cardiovascular-related mortality in hypertensive subjects with median arsenic exposure of 221–326 μg/L with the S allele genotype of the HO-1 gene compared with those without the S allele | Taiwan, <50–>750 μg/L (water)
| Hsieh et al. (2011) | Increased risk of carotid atherosclerosis with arsenic exposure >50 μg/L and PNP A-T haplotype and either the AS3MT genotype TC or glutathione S-transferase omega 1 (GSTO) haplotypes CAA/ht3 (CAG) or AGG | Taiwan, <10–>50 μg/L (water)
| Wu et al. (2014) | Increased risk of cIMT with arsenic exposure ≥40.4 μg/L and polymorphisms in APOE, arsenic 3-methyltransferase (AS3MT), purine nucleoside phosphorylase (PNP), and tumor necrosis factor (TNF) genes | Bangladesh, 76.4 μg/L (mean water)
| Farzan et al. (2015c) | Higher annual pulse pressure associated with arsenic exposure and CYBA rs3794624 variant genotype after adjustment for multiple testing | Bangladesh, 102.0 μg/L normal SBP; 91.9 μg/L prehypertensive to hypertensive (mean water)
| Hsueh et al. (2005) | Increased risk of hypertension with cumulative arsenic exposure ≥10,500 μg/L-yr and polymorphisms of manganese superoxide dismutase (MnSOD) (T-to-C substitution in mitochondria targeting sequence), NADPH oxidase (C-to-T substitution of the C242T site), and endothelial nitric oxide synthase (eNOS) (G-to-T substitution of G894T site) | Taiwan, 700–930 μg/L (median water)
Life stages | Yuan et al. (2007) | Higher risks for mortality from acute myocardial infarction (mortality rate ratio = 3.23, 95% CI: 2.79–3.75) for men 30 to 49 yr of age exposed in utero or in childhood to approximately 580 μg/L arsenic compared with those not exposed in utero or in childhood | Chile, 580 μg/L (mean water 1958–1970)
| Tseng et al. (2005) | Significantly increased risk of peripheral vascular disease in older compared with younger residents, likely due to older resident’s decreased capacity to methylate arsenic to DMA | Taiwan, 700–930 μg/L (median water)
| Smith et al. (2012) | Significantly higher risk for mortality from acute myocardial infarction (standardized mortality ratio = 2.1, 95% CI: 1.8, 2.5) for residents 30 to 49 yr of age exposed in utero or in childhood during the high-exposure period (1958–1970) compared with the general population | Chile, mean drinking water: before 1958: 90 μg/L; 1958–1970: 870 μg/L; 1970– 1980: 110 μg/L; 1980–2012: <10 μg/L
Nutrition | Chen et al. (2007) | Subjects with below average dietary intake of vitamin B and folate had an increased risk of hypertension with increasing arsenic levels | Bangladesh, 0.1–684 μg/L (water)
Sex | Lewis et al. (1999) | No difference in hypertensive heart disease between men (SMR = 2.20, 95% CI: 1.36–3.36) and women (SMR = 1.73, 95% CI: 1.11–2.58), but association for all other heart disease increased in women only (SMR 1.43 compared with 0.94 in men) | United States, 14–166 μg/L (median water)
| Tollestrup et al. (2003) | Significantly elevated hazard ratio (HR = 1.77, 95% CI: 1.21–2.58) for ischemic heart disease for boys living more than 10 yr <1.6 km from copper smelter and arsenic refinery site, but not elevated (HR = 1.69, 95% CI: 0.81–3.51) in girls | United States, <1.0–>10 yr (# yr spent at residence)
| Tseng et al. (2005) | Significantly increased risk for peripheral artery disease in men compared with women, reportedly due to women’s increased capacity to methylate arsenic to dimethylarsenic acid (DMA) | Taiwan, 700–930 μg/L (median, water)
| Rahman et al. (2014) | Significantly increased risk of stroke with arsenic exposure >50 μg/L for the whole population (HR = 1.35, 95% CI: 1.04–1.75) and women alone (HR = 1.72, 95% CI: 1.15–2.57) but not for men alone (HR = 1.07, 95% CI: 0.75–1.51) | Bangladesh, <10–>50 μg/L (water)
| D’Ippoliti et al. (2015) | Significantly increased risk of mortality due to myocardial infarction and peripheral arterial disease, respectively, with cumulative arsenic exposure in males but not in women; a higher risk of mortality due to stroke in women compared with men | Italy, 0.5–80.4 μg/L (water)

#### Evidence Judgment

A large robust body of epidemiological studies supports the conclusion that the currently available evidence demonstrates that iAs causes DCS in humans (see Table 3-3) given sufficient exposure conditions.^17^ This is consistent with the conclusion of the NASEM, which rated IHD as Tier 1 based on the strength of the evidence (NRC, 2013). The evidence from the large high and medium confidence longitudinal studies consistently reported associations with IHD incidence and mortality, while the results for hypertension were also largely consistent. These large studies were conducted in different countries and studied populations with high and low (<100 μg/L) arsenic concentrations in drinking water. (Supplemental figures of results from studies documenting adverse effects from exposure to inorganic arsenic in drinking water at concentrations less than or equal to 100 μg/L, as described in 1.6.3, are available in Appendix B.5.). The studies adjusted for key confounders including BMI, smoking status, and education level, potential risk factors for ischemic heart and cardiovascular disease that may be related to the distribution of arsenic or influence health effects of arsenic exposure.

Consistent exposure-dependent associations of iAs concentration in drinking water with IHD-related morbidity and mortality were observed (Figure 3-5). There is evidence of a dose-response gradient across studies, including IHD incidence and mortality, CVD, hypertension, atherosclerosis, and electrocardiogram abnormalities. The evidence is from several studies with longitudinal designs that establish the temporality between exposure and effect, and in which important confounding factors were controlled in the analyses (Farzan et al., 2015a; James et al., 2015; Moon et al., 2013; Chen et al., 2011b; Sohel et al., 2009). Consistent evidence from epidemiological studies of associations between iAs and increases in cIMT, an indicator of preclinical atherosclerosis, provides coherence and biological plausibility for associations with cardiovascular-related morbidity and mortality (Chen et al., 2013b; Osorio-Yáñez et al., 2013; Chiou et al., 2001b; Chen et al., 2013b; Chiou et al., 2001b; Osorio-Yáñez et al., 2013). Larger effect estimates among those with genotypes linked to regulation of atherosclerosis also support the biological plausibility for observed associations (Chen et al., 2012b; Huang et al., 2009; Li et al., 2009).

As shown in Figure 3-10 and Figure 3-11, associations between iAs exposure and hypertension, which is a risk factor for IHD, were fairly consistent. Although no association of time-weighted average iAs exposure with hypertension was observed in the HEALS cohort of Bangladesh, associations with increased SBP and DBP (Jiang et al., 2015; Jiang et al., 2015) and PP in subgroups with low nutrient intake (Chen et al., 2007; Chen et al., 2007) were observed. In addition, exposure to arsenic was associated with increased blood pressure in a prospective cohort of pregnant women in the New Hampshire Birth Cohort (Farzan et al., 2015b) (well water concentration mean(SD): 4.3(11.0) μg/L), and cross-sectionally in children in Mexico (drinking water-arsenic concentrations ranging from 3 to 135 μg/L) (Osorio-Yáñez et al., 2015). Other lines of evidence are limited but provide some support for coherence and biological plausibility for an effect of iAs exposure on blood pressure. Associations with endpoints indicating sympathetic hyperreactivity, which are considered early risk factors for hypertension, are reported in an arsenic-exposed population of normotensive men in Romania (Kunrath et al., 2013). Associations between iAs and QT prolongation in humans, which co-occurs with LVH and hypertension, also lend additional support to the overall evidence of an iAs effect on hypertension (Chen et al., 2013d; Mordukhovich et al., 2009; Wang et al., 2009).

Some evidence from epidemiological studies indicates iAs exposure could be associated with cerebrovascular disease and stroke, although findings across the available studies on this outcome are largely inconsistent. An association of stroke-related mortality was observed in a prospective study in Bangladesh where concentrations of iAs in drinking water ranged from 0.5 to 644 μg/L (median 86.8) (Rahman et al., 2014); and in Italy where arsenic concentrations were lower (mean 19.3 μg/L) (D’Ippoliti et al., 2015). Positive, imprecise, or null associations were observed across other studies of varying design, however.

Overall, there is robust evidence from a large set of high and medium confidence epidemiological studies of varied design showing that the currently available evidence demonstrates that iAs exposure causes DCS in humans given sufficient exposure conditions. This conclusion is based on studies of humans that assessed a variety of exposure levels (e.g., including < 20 μg/L). The strongest evidence derives from studies of IHD incidence and mortality and, to a lesser extent, hypertension. Coherent evidence is provided by studies linking arsenic exposure to related conditions such as atherosclerosis and repolarization abnormalities. The epidemiological evidence base includes multiple, large, high-quality longitudinal studies that control for important confounders and adequately consider other forms of bias. Diseases of the circulatory system are therefore considered for dose-response analysis as discussed in Section 3.3 (Hazard Considerations for Dose-Response Analysis) and Section 4 (Dose-Response Analysis).

Table 3-3 Evidence profile table for epidemiological evidence on iAs and diseases of the circulatory system

Evidence stream summary and interpretation
Evidence from studies of exposed humans
Studies | Summary of key findings | Factors that increase certainty | Factors that decrease certainty | Evidence synthesis judgment(s)
Cardiovascular disease; Ischemic heart disease; 25 medium or high confidence studies | Large, prospective cohort studies support exposure-dependent associations of relatively low exposures to iAs in drinking water (<100 μg/L) with incidence and mortality; associations observed in other study design including crosssectional, and ecological “natural experiments” across populations including U.S., Bangladesh, China, Taiwan, and Mexico. | - Studies are medium or high confidence.; - Consistency – within and across study types, including meta-analyses.; - Dose-response gradient – observed in most studies.; - Large or concerning magnitude of effect – large odds ratios (e.g., >4–6) in some studies.; - Coherence with findings for related endpoints/IHD risk factors such as hypertension, atherosclerosis | - No factors noted. | ⊕⊕⊕; Robust
Hypertension; 31 medium or high confidence studies | Cohort studies across geographically diverse populations report positive associations, which might be more pronounced with higher exposure (>50 μg/L). | - Studies are medium or high confidence.; - Consistency – generally reported with metrics indicating recent exposure to iAs (or cumulative exposure in currently exposed populations) across different life stages, including adults, pregnant women, and children.; - Dose-response gradient observed in most studies.; - Large or concerning magnitude of effect – large odds ratios (e.g., >2–4) in some studies.; - Coherence across related endpoints such as QT prolongation | - No factors noted. | ⊕⊕⊕; Robust
Cerebrovascular disease and stroke; 11 medium or high confidence studies | Some well-conducted studies report positive associations. However, inverse or null associations were also observed across other studies of varying design. | - Studies are medium or high confidence.; - Dose-response gradient observed in many studies, though more consistently observed in populations with higher (>100 μg/L) concentrations of iAs in drinking water | - Unexplained inconsistency across studies | ⊕⊕⊙; Moderate

### 3.2.2 Diabetes

#### Database Overview

In 2013, the NRC concluded that low-to-moderate levels of inorganic arsenic are associated with diabetes based on evidence from human studies (NRC, 2013). As a result, evaluation of diabetes was categorized as a priority outcome and recommended for consideration for dose-response analysis in the IRIS Toxicological Review. On the basis of on the analysis of epidemiological evidence, the strength of evidence judgment for a causal association was considered “robust.” Robust evidence from humans leads to the strongest evidence integration conclusion of evidence demonstrates (U.S. EPA, 2022). This section summarizes the review of the currently available evidence demonstrating that iAs causes type 2 diabetes in humans.

There are 112 epidemiologic publications that report on the relationship between arsenic exposure and diabetes (see Figure 3-22). Fifty-seven of the 112 studies were considered medium or high confidence, 13 were considered low confidence due to limitations noted in HAWC (https://hawc.epa.gov/assessment/100500243/), and 41 studies identified in the 2022 search update were considered further for dose-response but were not factored into the qualitative considerations and synthesis (see Section 1.6.1). Because of the abundance of the evidence base, the subsequent synthesis is focused on the medium and high confidence studies (see Figure 3-23 and Figure 3-24). Citations of studies broken down by confidence level and studies identified in the 2022 update can be accessed via the interactive HAWC literature tag-tree visual presented in Figure 3-22. While the majority of these epidemiologic studies examined drinking water exposure to arsenic; others reported arsenic levels in biomarkers of exposure such as urine and blood. Further, epidemiologic data related to risk modifiers (e.g., genetic variation, cigarette smoking) are also presented. The information below is organized by study design.

Figure 3-22 Literature tree of epidemiological studies that assessed diabetes (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Diabetes/))

Figure 3-23 Study evaluation ratings for cross-sectional studies evaluating diabetes (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Diabetes-SQE-for-Cross-Sectional-Studies/))

Figure 3-24 Study evaluation ratings for case-control, cohort, and ecological studies evaluating diabetes (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Diabetes-SQE/))

#### Evidence from Epidemiological Studies

Studies used a variety of methods to determine diabetes status; diabetes was defined based on several diagnostic measurements or conditions, including level of fasting glucose or 2-hour glucose measurements, HbA1c values, glucosuria, metabolic syndrome, insulin levels, impaired glucose tolerance, self-reported physician diagnosis, current use of diabetes medication, and insulin resistance. Almost all studies required participants to have one validated clinical indicator of a diabetes diagnosis based on WHO or American Diabetic Association criteria. For this evaluation, glucosuria, defined as excretion of glucose in the urine, was not considered an adequate diagnostic indicator of diabetes status. Studies that used this diagnostic indicator as the sole criterion for diabetes diagnosis were considered critically deficient, rated as low and not considered further (Guo et al., 2007). Results, discussion, and evidence judgment focus on type 2 diabetes, as the evidence base is primarily for this outcome. Type 1 diabetes and gestational diabetes studies are included in study evaluation but are discussed in the ‘Other’ category.

Overall, the association between arsenic exposure and diabetes was mostly positive and consistent across studies (see Figure 3-25 and Figure 3-26). The strongest evidence comes from cohort and case-control studies, which generally demonstrated a positive association between arsenic exposure and incidence of diabetes mellitus or diabetes-related mortality (D’Ippoliti et al., 2015; Shapiro et al., 2015; Farzan et al., 2016). Most studies adjusted for relevant confounders (e.g., age, sex, BMI, smoking) and still observed an independent association with arsenic. The included studies were conducted in the general population of the United States as well as in both the general population and in occupational settings in various regions of the world including Bangladesh, Taiwan, China, Canada, Denmark, Italy, and Mexico.

##### Case-control and cohort studies

The literature review identified 20 case-control and cohort medium or high confidence studies (Yuan et al., 2018; Tseng et al., 2000; Spratlen et al., 2018; Simić et al., 2017; Pan et al., 2013b; Nizam et al., 2013; Li et al., 2017; Lewis et al., 1999; Kuo et al., 2015; Kuo et al., 2018; Kim et al., 2013; James et al., 2013; Hsu et al., 2013; Grau-Pérez et al., 2017; Grau-Perez et al., 2017; D’Ippoliti et al., 2015; Coronado-González et al., 2007; Chen et al., 2012a; Bräuner et al., 2014) that evaluated the association between iAs exposure and type 2 diabetes. The findings generally demonstrated a positive association between arsenic exposure and incidence of diabetes; the hazard ratios were usually around 2 when compared with those in lowest exposure category, often ≤10 μg/L (see Figure 3-25). A dose-response gradient was observed within some [e.g., (Pan et al., 2013b; James et al., 2013; Grau-Perez et al., 2017; Ettinger et al., 2009; D’Ippoliti et al., 2015; Coronado-González et al., 2007; Chen et al., 2012a; Bräuner et al., 2014)] but not all studies, with stronger effects observed in higher exposure regions. While many of these studies examined drinking water exposure to arsenic as a function of consumption duration and well arsenic concentrations, Tseng et al. (2000) conducted a prospective cohort study in an arseniasis-endemic village of Taiwan and identified a positive dose-response relationship between arsenic ingestion and diabetes incidence with a relative risk (RR) of 2.1 (95% CI: 1.1, 4.2) for cumulative drinking water exposures ≥17,000 μg/L*year. In Denmark, Bräuner et al. (2014) conducted a prospective cohort study that identified an incidence rate ratio (IRR) of 1.03 (95% CI: 1.01, 1.06) per 1-μg/L increase in average arsenic drinking water levels when diabetes diagnoses were defined by blood glucose levels, use of diabetes medication, and other inclusion criteria of the Danish National Diabetes Register. However, when a stricter definition of diabetes was used (i.e., when cases were excluded if diabetes was defined only by blood glucose levels), the RRs were somewhat attenuated (IRR = 1.02; 95% CI: 0.99, 1.05). When the study population was evaluated by quartiles, the IRR was 1.19 (95% CI: 1.09, 1.31) in the highest quartile of exposure (>1.82 μg/L) compared with the lowest exposure group (<0.57 μg/L). In a Chinese population, a case-control study (Li et al., 2017) found plasma arsenic (median: 0.615 μg/L) to be associated with diabetes mortality, while another case-control study (Yuan et al., 2018) observed a null association between plasma arsenic concentrations (median (IQR): 2.04 (1.25, 3.63) μg/L) and type 2 diabetes among Chinese senior adults.

Grau-Perez et al. (2017) also evaluated the prospective association of arsenic exposure and metabolism with type 2 diabetes and insulin resistance (IR) in the SHFS. Incident diabetes status was determined by HOMA2-IR (fasting glucose ≥126 mg/dL), self-reported physician diagnosis or self-reported use of insulin or oral diabetes treatment. Median urine ∑As a baseline was 5.9 μg/L. The authors reported that over 10,327 person-years of follow-up, 252 participants developed diabetes (N = 1,838). Median HOMA2-IR at baseline was 1.5. The hazard ratio [95% (CI)] for incident diabetes per an interquartile range increase in ∑As was 1.57 (95% CI: 1.18, 2.08) in participants without prediabetes at baseline. The authors found that while iAs metabolism was not associated with incident diabetes, arsenic metabolism with HOMA2-IR results differed among study participants according to vitamin B intake and AS3MT genetic variant, indicating a role for nutrition as a risk modifier. Finally, ∑As was positively associated with HOMA2-IR at baseline but negatively with HOMA2-IR at follow-up (initial 2–3 years and 7–10 years). Increased MMA% was associated with lower HOMA2-IR when either iAs% or DMA% decreased. Further, a positive association was observed between arsenic exposure and incident diabetes among participants without baseline prediabetes and a cross-sectional and prospective association was observed between low MMA% and higher HOMA-IR measures, but not with incident diabetes. Kuo et al. (2018) a 15-year birth cohort follow-up study in Taiwan, did not find significant associations between postnatal iAs exposure (median urinary arsenic at age 2: boys: 22.3 μg/L; girls: 17.7 μg/L) and adolescent HOMA-IR.

One study of metabolic syndrome, a related outcome defined as having at least three of five risk factors: large waistline, high triglycerides, low HDL, high blood pressure, and high fasting blood sugar, reported no association (Chen et al., 2012a). The authors also measured insulin sensitivity (Chen et al., 2012a). While an increase was observed in the OR for metabolic syndrome (1.73 for cumulative arsenic >18,900 μg/L*yr [versus <12,600 μg/L*yr] and 1.24 for well water arsenic concentration >767.65 μg/L [versus <700 μg/L]), the results were not statistically significant and may be due to a smaller sample size relative to other studies (N = 287). There also was not a correlation between cumulative arsenic exposure and insulin sensitivity. A more recent prospective cohort study by Spratlen et al. (2018) evaluated the associations of baseline arsenic exposure (i.e., urinary arsenic levels, median(IQR): 6.5 (4.2–10.8) μg/L) and metabolism (relative percentage of arsenic species over their sum, (∑As)) with incident metabolic syndrome (MetS) and its individual components (i.e., elevated waist circumference, elevated triglycerides, reduced high-density lipoprotein cholesterol, hypertension, and elevated fasting plasma glucose) in the Strong Heart Family Study (SHFS).^18^ The authors found that an interquartile range increase in ∑As arsenic exposure was associated with a 1.19-fold (95% Cl: 1.01, 1.41) greater risk of elevated fasting plasma glucose concentration but not with other individual components of the MetS or MetS overall.

Evidence from retrospective cohort studies also largely reported a positive association between arsenic exposure and diabetes. D’Ippoliti et al. (2015) reported an association between cumulative arsenic (CAI) exposure levels >804.0 μg with diabetes mortality in females (hazard ratio (HR) of 2.56 CI: 95% 1.43, 4.57 p < 0.001).^19^

Figure 3-25 Case-control/Cohort epidemiologic studies examining the association between inorganic arsenic and diabetes (a) ratio measures, drinking water, categorical exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Diabetes-Case-controlCohort-water/); (b) ratio measures, other biomarker, categorical exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Diabetes-Case-controlCohort-biomarker-categorical/); (c) ratio measures, urine, categorical exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Diabetes-case-controlcohort-difference-measur-8a21/); (d) ratio measures, urine, continuous exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Diabetes-case-controlcohort-ratios-urine-cont-c125/) (see interactive data graphic)

(a) Ratio measures, drinking water, categorical exposure

(b) Ratio measures, nonurinary biomarkers, categorical exposure

(c) Ratio measures, urine, categorical exposure

(d) Ratio measures, urine, continuous exposure

Case-control studies largely observed an association between iAs exposure in drinking water and increased diabetes risk. One prospective study, James et al. (2013) used geospatial mapping of drinking water arsenic concentrations to ascertain lifetime exposure levels (<150 μg/L) relative to diabetes prevalence in the San Luis Valley Diabetes Study participants in rural Colorado, a strong study design for temporal relevance of arsenic drinking water exposure. The authors concluded that risk of type 2 diabetes increased by 27% for each 15-μg/L increase in time-weighted average (TWA) residential iAs water concentration (HR=1.27; 95% CI: 1.02, 1.64). Kim et al. (2013) observed that arsenic exposure was associated with an increased OR (2.14; 95% CI: 1.19, 3.85) for developing type 2 diabetes when comparing the highest three exposure quartiles (4.6–36 μg/L; urinary iAs) to the lowest quartile in the United States. Pan et al. (2013b) reported an increased OR in the highest two quartiles of arsenic exposure (15.6–170 μg/L in drinking water, OR=3.07, 95% CI: 1.38, 6.85; ≥170.1 μg/L in drinking water, OR=4.51, 95% CI: 2.01, 10.09) compared with the lowest quartile of exposure in a Bangladeshi population. Kim et al. (2013) was based on a single spot urine sample to determine arsenic concentration and therefore reflects exposure at one point in time, but groundwater inorganic arsenic is not expected to fluctuate substantially over time (Kim et al., 2013). In a population in Bangladesh, measurement of arsenic exposure occurred prior to diabetes development, with similar associations seen with both drinking water exposure (median 15.2 μg/L at baseline; 8.73 μg/L at follow-up) and toenail biomarker (Pan et al., 2013b). From another study in Bangladesh, Nizam et al. (2013) examined the metabolism of arsenic in diabetics (mean arsenic in drinking water: 85.1 μg/L) as compared with nondiabetics (mean arsenic in drinking water: 85.8 μg/L) and did not observe a significant difference in urinary arsenic metabolites between the groups.

Coronado-González et al. (2007) evaluated subjects from an arseniasis-endemic region from Coahuila, a northern state of Mexico with a high incidence of diabetes. The analysis by Coronado-González et al. (2007) identified a positive association for type 2 diabetes in participants with urinary arsenic concentrations 63.5–104 μg/g creatinine (OR = 2.16; 95% CI: 1.23, 3.79), and a three times greater risk for those with >100 μg/g creatinine (OR = 2.84; 95% CI: 1.64, 4.92); values not adjusted for creatinine presented similar results (data not shown).

Consistent findings were seen in other highly exposed areas, like Taiwan (Hsu et al., 2013), as well as lower-exposed areas, including the Northern Plains (Kuo et al., 2015) in the U.S. (median (IQR) urine concentration of inorganic arsenic plus methylated species: 10.2 (6.1–17.7) μg/L). In the U.S. (Kuo et al., 2015), higher iAs% and DMA% in urine, when MMA% decreased, was associated with diabetes incidence in the Strong Heart Study [HR (95% CI) of diabetes incidence per 5% increase in arsenic metabolism biomarkers: 1.00 (0.89–1.12) for iAs% and 1.07 (1.00–1.15)] for DMA%. Null results were observed in Utah, U.S. (Lewis et al., 1999).

Two studies based on data from multiple health surveys of the general adult population in Norway (Hansen et al., 2017; Simić et al., 2017) reported no associations between iAs and diabetes in this Norwegian population (median iAs = 0.05 μg/L in drinking water).

##### Cross-sectional studies

Thirty-two (medium and high confidence) cross-sectional studies (Zierold et al., 2004; Yang et al., 2017; Xiao et al., 2018; Velmurugan et al., 2018; Steinmaus et al., 2009; Rhee et al., 2013; Rahman and Axelson, 2001; Peng et al., 2015a; Park et al., 2015; Navas-Acien et al., 2008, 2009a; Mendez et al., 2016; Liu et al., 2016; Lin et al., 2014; Li et al., 2013a; Lampron-Goulet et al., 2017; Lai et al., 1994; Islam et al., 2012b; Huang et al., 2014; Gunduz et al., 2017; Gribble et al., 2012; Grau-Perez et al., 2018; Feseke et al., 2015; Feng et al., 2015; Drobná et al., 2013; Del Razo et al., 2011; Currier et al., 2014; Claus Henn et al., 2016; Chen et al., 2010c; Chen et al., 2011a; Adams et al., 2015) evaluated arsenic exposure in association with diabetes (see Figure 3-25). One of the oldest studies to identify a possible relationship between arsenic exposure and increased risk of diabetes was conducted by Lai et al. (1994). The study authors were interested in examining occurrence of diabetes related to arsenic exposure because this health outcome is closely related to vascular and peripheral artery disease (e.g., Blackfoot disease) that has been observed in high-exposure, arsenic-endemic areas. More recent cross-sectional studies of populations across the world consistently report a positive relationship between arsenic exposure and diabetes (Lampron-Goulet et al., 2017; Currier et al., 2014; Feng et al., 2015; Feseke et al., 2015; Drobná et al., 2013; Rhee et al., 2013; Islam et al., 2012b; Del Razo et al., 2011; Gribble et al., 2012; Lin et al., 2014; Yang et al., 2017; Grau-Perez et al., 2018; Velmurugan et al., 2018; Gunduz et al., 2017; Xiao et al., 2018; Zierold et al., 2004;Park et al., 2015). These studies evaluated associations with arsenic concentration in drinking water, cumulative arsenic exposure measures, or internal biomarkers of exposure (primarily urine). Generally, the exposure definition either involved a single biomarker measurement or a metric reflecting the combination of data from both biomarker and drinking water samples. In the few studies that looked at cumulative exposure, water consumption data and water arsenic concentration was often the only measure(s) used (e.g., weighted average (μg/L) as a function of drinking durations and well arsenic concentrations). Although the relevance of exposure measured cross-sectionally to the development of diabetes is less certain, the results of these studies were largely consistent across exposure measure types and are consistent with the findings of the cohort and case-control studies.

Currier et al. (2014) examined associations between arsenic species (including methylarsonate [MAIII) and dimethylarsinite [DMAIII]) in exfoliated urothelial cell (an alternative to the measures of iAs in urine) and the prevalence of diabetes among residents of Chihuahua, Mexico (mean sum of As species in urine: 109.7 ng As/specific gravity unit). They found a positive OR for the sum of arsenic species (1.24; 95% CI: 0.91, 1.68) and positive, significant ORs for iAs III, MA III, iAs(III+V), DMA/MA, and DMA/iAs but not for other species, suggesting that trivalent iAs species may be responsible for associations between iAs exposure and diabetes. Additional studies by these authors further observed a significant increase in OR (i.e., 1.13 95% CI: 1.05–1.22) per 10 μg/L increase in drinking water in an arsenicosis-endemic area of Mexico but did not find an increase when evaluating cumulative exposures by ppm-years (Del Razo et al., 2011; Mendez et al., 2016). The authors suggest that this was likely due to changes in levels of iAs in drinking water supplies in recent years as a result of government interventions to reduce exposure. Drobná et al. (2013) conducted genotyping that focused on six polymorphic sites of AS3MT and reported that subjects with a variant type M287T and G4965C polymorphisms had higher levels of DMA(III) and were more susceptible to developing diabetes, providing support for the role of arsenic methylation and diabetes risk.

Additional cross-sectional studies provided further support for the association between iAs and diabetes risk. For example, Gribble et al. (2012) reported on a large American Indian population residing in the U.S. (Strong Heart Study, n ~ 4,000) with increasing adjusted prevalence ratios for diabetes in relation to quartiles of urinary arsenic concentrations ranging from <7.9 to >24.2 μg/L. Also in the U.S., using NHANES data, urinary arsenic was associated with increased prevalence of type 2 diabetes (Navas-Acien et al., 2009a; Navas-Acien et al., 2008); and Adams et al. (2015) observed an association between urinary arsenic (mean: 18.7 μg/L) and type 2 diabetes in older Hispanic adults living in southern New Mexico. However, Steinmaus et al. (2009) saw no increased risk of diabetes with arsenic exposure (median: 7.6 μg/L) in NHANES adults; and Peng et al. (2015a) when examining urinary arsenic (median: 7.01 μg/L) and insulin resistance in NHANES adolescents, did not observe an association. A dose-response gradient was observed within a number, but not all, studies (Xiao et al., 2018; Velmurugan et al., 2018; Rhee et al., 2013; Navas-Acien et al., 2008; Li et al., 2013a; Lai et al., 1994; Islam et al., 2012b; Gribble et al., 2012; Grau-Perez et al., 2018; Feseke et al., 2015; Feng et al., 2015; Chen et al., 2011a).

In Korea, Rhee et al. (2013) reported a statistically significant OR in the highest quartile of arsenic exposure (≥193.4 μg/g creatinine urinary total arsenic; OR = 1.56; 95% CI: 1.03, 2.36) compared with the lowest exposure group (<80.7 μg/g creatinine); ORs exhibited a positive linear trend when comparing quartiles. In KHANES (the Korean National Health and Nutrition Examination Survey), Kim and Lee (2011) observed an association between urinary arsenic concentration and diabetes in adults. Lin et al. (2014) examined the association between urinary arsenic and insulin resistance in obese children (mean total As concentration: 23.01 μg/L) and adolescents using the homeostasis model assessment of insulin resistance (HOMA-IR) index and found that for all students in the summary model, HOMA-IR levels were significantly increased with increases in total arsenic concentrations.

Grau-Perez et al. (2018) examined the association of inorganic arsenic exposure and polymorphisms on diabetes-related genes in a representative sample from a population in Valladolid, Spain. The mean total arsenic in the study was 66.0 μg/g. The authors observed an OR (95% confidence interval) for diabetes when comparing the highest with the lowest tertile of total arsenic as follows: 1.76 (1.01, 3.09) and 2.14 (1.47, 3.11) (respectively, pre and post adjustments for arsenobetaine an organoarsenic found in seafood). A cross-sectional study in Taiwan reported an association between arsenic exposure and diabetes, which showed an increasing trend [OR(95% CI): 2.08(1.05–3.69) and 2.22(1.21–4.09) for urinary arsenic levels of >75–200 and >200 μg/g⁻^1^ creatinine, respectively, compared with reference <35 μg/g⁻^1^ creatinine](Chen et al., 2011a). In Cambodia, drinking water with arsenic levels above the median (907.25 μg/L) was associated with a statistically significant increase of diabetes in adults (Huang et al., 2014). In Bangladesh, Chen et al. (2010c) observed no association between well water or urinary arsenic and HbA1c level in the HEALS cohort; and Rahman and Axelson (2001) examined arsenic levels in drinking water (drinking water arsenic concentration range: nondetectable–2,040 μg/L) with presence of skin lesions as indicator of exposure and found an association between exposure to arsenic and glucosuria. In China, Li et al. (2013a) did not observe an association between arsenic exposure (range of arsenic in wells ranged from 0–760 μg/L) and type 2 diabetes.

Figure 3-26 Cross-sectional epidemiologic studies examining the association between arsenic and diabetes (a) ratio measures, drinking water, categorical exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Diabetes-cross-sectional-water-categorical/); (b) ratio measures, urine, categorical exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Diabetes-cross-sectional-water-categorical/); (c) ratio measures, urine, continuous exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Diabetes-cross-sectional-urine-continuous-exposure/update/) (see interactive data graphic)

(a) Ratio measures, drinking water, categorical exposure

(b) Ratio measures, urine, categorical exposure

(c) Ratio measures, urine, continuous exposure

##### Other: Type 1 diabetes and gestational diabetes

While the literature base largely examines type 2 diabetes, studies also examined type 1 diabetes (Grau-Pérez et al., 2017) and gestational diabetes (Shapiro et al., 2015; Peng et al., 2015b; Farzan et al., 2016; Ettinger et al., 2009; Claus Henn et al., 2016). These studies were largely consistent in demonstrating a positive association between arsenic exposure and incidence of type 1 diabetes mellitus or gestational diabetes.

In the type 1 diabetes study, Grau-Pérez et al. (2017) found folate intake to be a modifier of iAs metabolism associated with type 1 diabetes. The study examined the association of dietary intake of folate and vitamin B12 on iAs metabolism (specifically, one carbon metabolism) on the odds ratios of diabetes in youth (<20 years old). The results showed that ΣiAs was not associated with type 1 diabetes. However, the methylarsonite (MMA)% OR of type 1 diabetes showed an association between arsenic metabolism and type 1 diabetes (OR 1.80 (1.25–2.58) and 0.98 (0.70–1.38) for participants with plasma folate levels above and below the median (20.2 μg/L) (P for interaction = 0.02), respectively), indicating nutrition, in this case folate intake, may play a risk modifying role in iAs diabetes risk (Grau-Pérez et al., 2017; Grau-Pérez et al., 2017). Peng et al. (2015b) recruited participants from a maternity and childcare hospital in China and measured arsenic levels in newborn meconium samples. They reported positive dose-dependent trends between arsenic in the samples and incidence of maternal gestational diabetes. The trend for arsenic was significant for 2nd (OR = 3.28; 95% CI: 1.24, 8.71); 3rd (OR = 3.35; 95% CI: 1.28, 8.75); and 4th (OR = 5.25; 95% CI: 1.99, 13.86) quartiles of arsenic. In rural Oklahoma, U.S., inverse associations between arsenic (median (IQR) maternal and umbilical cord blood concentration: 1.4 (0.97 - 2.3) and 2.4 (1.8 - 3.3) μg/L, respectively) and all birth outcomes (birth weight, gestational age, birth weight for gestational age, head circumference) were observed to be stronger among women with impaired glucose tolerance (Claus Henn et al., 2016).

#### Mechanistic Observations and Biological Plausibility

The etiology of arsenic-associated diabetes is not clearly understood, but arsenic is hypothesized to interfere with pancreatic beta-cell function, insulin/glucose uptake and transport, insulin signaling pathways, and gluconeogenesis [Reviewed in (Díaz-Villaseñor et al., 2007)]. Other nonspecific effects include oxidative stress and interruption of calcium signaling. Details on these and other modes of action for arsenic are described in detail in Appendix A of the iAs Protocol. In one relatively recent review, Martin et al. (2017) identified four major mechanisms underlying arsenic-associated diabetes. These include: (1) inhibition of insulin dependent glucose uptake; (2) production of ROS leading to β-cell damage and chronic inflammation; (3) β-cell dysfunction due to increased ROS production; and (4) stimulation of glucogenesis. However, the authors noted the importance of the need to develop models that better assess the low-dose effects of arsenic on glucose homeostasis given that the evidence for mechanisms of arsenic-induced diabetes are based on studies that evaluated elevated arsenic levels in rodents and in vitro model systems that are not physiologically relevant to human environmental arsenic exposures. Nonetheless, these data could provide useful information on potential disruption of cellular homeostatic pathways associated with arsenic exposure.

Along with the epidemiological evidence from populations exposed to inorganic arsenic, in vivo and in vitro studies have shown that exposure to iAs can produce effects that correspond to insulin resistance and diabetogenic phenotypes. As discussed in Section 3.2.2 inorganic arsenic may induce diabetogenic effects through a variety of pathways including inhibition of insulin-dependent glucose uptake, interference with insulin signaling pathways, pancreatic beta-cell damage or dysfunction, and stimulation of hepatic glucogenesis [Reviewed in (Díaz-Villaseñor et al., 2007) and (Shakya et al., 2023)]. Other nonspecific effects include oxidative stress and interruption of calcium signaling as well as modulation of gene expression of genes involved in insulin signaling and adipocyte differentiation (Shakya et al., 2023) (see the iAs Protocol (link provided in Appendix A) for details on possible modes of action). As an example, Liu et al. (2014) exposed wild-type (C57BKS/J db/m) and C57BKS/Lepr^db^ mice exposed to 3 mg/L sodium arsenite for 16 weeks. C57BKS/Lepr^db^ are an in vivo model for diabetes. The authors showed that arsenic caused pancreatic beta-cell dysfunction and increased gluconeogenesis and oxidative damages in the livers of wild-type mice. Further, arsenic worsened glucose tolerance in the C57BKS/Lepr^db^ mice, suggesting that iAs exposure can cause prediabetic effects in normal individuals and worsen diabetic effects in diabetes individuals. Arsenic also caused a dose-dependent decrease in glucose uptake and insulin response in murine 3T3-L1 adipocytes and C2C12 myotubes exposed to 0, 0.5, 1, or 2 μM sodium arsenite for 8 weeks in vitro (Divya et al., 2015). These data provide evidence for the biological plausibility of inorganic arsenic to disrupt glucose-insulin homeostasis and induce diabetogenic effects.

#### Risk Modifiers

A review of the epidemiological studies discussed in this section, along with studies identified from a targeted literature search on modifying factors (see Section 3.10 of iAs Protocol) identified in Table 3-4, suggest that the following factors increase the risk of arsenic-associated diabetes:

- Genetic variation: The evidence suggests that individuals with certain polymorphisms that alter the metabolism of inorganic arsenic independently of excretion or absorption (e.g., GST, AS3MT) or increase the organ or cellular toxicity of inorganic arsenic might have an increased risk for diabetes from arsenic exposure. Specifically, polymorphisms in GSTO1, AS3MT, NOTCH2, and Calpain-10 have been identified as being associated with susceptibility to diabetes in arsenic-exposed populations. Polymorphisms in five diabetes-related genes (IL8RA, TXN, NR3C2, COX5A and GCLC) also showed a suggestive differential association of urine total arsenic with diabetes prevalence.
- Methylation capacity: The evidence suggests that decreased methylation capacity increases insulin sensitivity and may increase risk of diabetes. Contrary to what has been observed for other health outcomes, lower MMA% and higher DMA% in urine has been associated with increased risk of diabetes-related outcomes in populations from Taiwan, Mexico, and the U.S. (Chen et al., 2012a; Currier et al., 2014; Grau-Pérez et al., 2017).
- Nutrition: The evidence suggests that individuals with high BMI may be at increased risk of diabetes. Increased BMI and smoking status have been examined as factors in multivariate analyses of diabetes risk and arsenic exposure and might have potential additive affects. Vitamin B intake and folate levels may also increase risk of diabetes.
- Smoking: The evidence suggests that smokers may have an increased risk for diabetes from arsenic exposure. Evidence indicates a synergistic effect between arsenic and smoking from one study. There was a significant interaction between smoking and arsenic exposure for past or current male smokers exposed to higher levels of arsenic in drinking water (≥15.5 μg/L) compared with nonsmokers exposed to lower levels (<15.5 μg/L) (Pan et al., 2013b). Smoking history data were only available in men.

Table 3-4 Risk modifiers for diabetes from selected epidemiologic studies

Risk modifiers | References | Finding | Population, exposure level
Genetic variation | Chen et al. (2012a) Drobná et al. (2013) | GSTO1, AS3MT polymorphisms can affect arsenic methylation status. | Taiwan, 700–930 mg/L-yr, range (water); Mexico 43 μg/L, mean (water)
| Pan et al. (2013a) | NOTCH2 polymorphism increased susceptibility to diabetes. | Bangladesh, ≤1.7–≥170.1 μg/L, range (water)
| Díaz-Villaseñor et al. 2013 | Calpain-10 polymorphism can impair pancreatic beta-cell function and insulin sensitivity. | Mexico, 2.8–131.5 μg/L, range (water)
| Grau-Perez et al. (2018) | The analysis of polymorphisms in five diabetes-related genes (IL8RA, TXN, NR3C2, COX5A and GCLC) showed a suggestive differential association of urine total arsenic with diabetes prevalence. | Spain, geometric mean 66.0 μg/g total urinary arsenic
Methylation | Chen et al. (2012a) | Insulin sensitivity significantly increased at low methylation levels. | Taiwan, 700–930 mg/L-yr, range (water)
| Currier et al. (2014) | High DMA/MA ratio in urine may be a risk factor for diabetes. | Mexico, 55.2 μg/L, mean (water)
| Grau-Perez et al. (2017) | Lower MMA% associated with increased insulin resistance | United States, <50 μg/L (water)
Nutrition | Su et al. (2012) Pan et al. (2013b) | BMI can affect methylation capacity and risk of diabetes; potential additive effect of high BMI and arsenic exposure (increased OR in overweight/obese individuals). | Taiwan, ND–4 μg/L, range (water); Bangladesh, ≤1.7–≥170.1 μg/L, range (water)
| Grau-Perez et al. (2017) | Arsenic metabolism with HOMA2-IR results differed among study participants according to vitamin B intake and AS3MT genetic variant | USA, American Indian Population, 5.9 μg/L total urinary arsenic
| Grau-Pérez et al.(2017) | Folate levels at or below median levels increased association between arsenic metabolism and type 1 diabetes due to increase %MMA | USA, American Indian Population, 5.9 μg/L total urinary arsenic
Smoking | Pan et al. (2013b) | Increased OR in men who smoke. Smoking history only available in men. | Bangladesh, ≤1.7–≥170.1 μg/L, range (water)

#### Evidence Judgment

The currently available human evidence is considered robust and the evidence demonstrates that iAs causes type 2 diabetes in humans (see (https://hawcprd.epa.gov/summary/assessment/100500243/tables/Diabetes/) Table 3-5) given sufficient exposure conditions.^20^ This conclusion is based on studies of humans that assessed oral exposure to arsenic from contaminated drinking water. Diabetes diagnoses were generally based on glucose measurements, use of diabetes medication, or self-reported diagnoses with medical record verification. Study subjects included populations across three continents with different ethnic backgrounds; from arsenic-endemic areas (e.g., Bangladesh, Taiwan; >100 μg/L arsenic in drinking water) and those from geographical areas with comparatively lower levels of arsenic exposure (e.g., Denmark, United States; <100 μg/L arsenic in drinking water and including <20 μg/L).

A strong evidence base demonstrating arsenic exposure causes type 2 diabetes in humans comes from consistency across different study designs, cohort, case-control studies, and cross-sectional, which were largely consistent in demonstrating a positive association between arsenic exposure and incidence of type 2 diabetes and diabetes-related mortality. Trivalent arsenic species may also be responsible for associations between chronic iAs exposure and diabetes. A dose-response gradient was observed in many studies; several studies reported a strong exposure response gradient with hazard ratios usually around 2 when compared with those in lowest exposure category, often ≤10 μg/L, and a temporal relationship was evident in several prospective cohort studies in which prolonged arsenic exposure was associated with diabetes. There is coherence with type 1 and gestational diabetes findings. Studies also highlighted differences in the association between iAs exposure and diabetes for susceptible populations, such as genetic variation (e.g., individuals that carry polymorphisms in AS3MT gene); nutritional status; smoking status and methylation capacity.

Overall, the currently available epidemiologic evidence demonstrates that iAs causes type 2 diabetes in humans given sufficient exposure conditions. This conclusion is based on both higher and lower exposure scenarios, with studies of humans that assessed exposure levels much lower than 100 μg/L (<20 μg/L). (Supplemental figures of results from studies documenting adverse effects from exposure to inorganic arsenic in drinking water at concentrations less than or equal to 100 μg/L, as described in 1.6.3, are available in Appendix B.5.). This conclusion is based on a large set of case-control, cohort and cross-sectional studies that consistently reported associations with diabetes in populations exposed to iAs contaminated water ranging from ≤1.7 mg/L (range in water) to 930 mg/L-yr, (range water) exposure and, therefore, is considered for dose-response analysis (see Section 4.3.8).

Table 3-5 Evidence profile table for epidemiological evidence on iAs and type 2 diabetes

Evidence stream summary and interpretation
Evidence from studies of exposed humans
Studies | Summary of key findings | Factors that increase certainty | Factors that decrease certainty | Evidence synthesis judgment(s)
57 medium or high confidence studies | Generally consistent, positive associations with T2D across diverse populations and study designs in both higher and lower exposure scenarios. Some evidence for exposure-dependent changes within and across studies with well-characterized exposures, long duration exposures with sufficient follow-up for latency. | - Studies are medium or high confidence.; - Consistency – of strong positive associations in populations across three continents, primarily at relatively low exposures to iAs in drinking water (<100 μg/L) Doseresponse gradient – observed across many studies.; - Large or concerning magnitude of effect-observed in some studies (e.g., ratio measures >2–>3); - Coherence – with type 1 diabetes and gestational diabetes findings | - No factors noted. | ⊕⊕⊕; Robust

### 3.2.3 Fetal, Newborn, and Infant Health Outcomes

#### Database Overview

The NRC identified early life as a potential critical window of susceptibility to toxic effects from arsenic exposure and concluded that low-to-moderate levels of inorganic arsenic are associated with pregnancy and birth outcomes based on evidence from human studies (NRC, 2013). As a result, evaluation of fetal, newborn, and infant health outcomes is under consideration for dose-response analysis in the IRIS Toxicological Review. On the basis of the analysis of epidemiological evidence using the methods described in the protocol (link provided in Appendix A), the strength of evidence judgment for a causal association was considered “moderate.” Moderate evidence from humans leads to an evidence integration conclusion of evidence indicates (likely) (U.S. EPA, 2022). This section summarizes the review of the moderate evidence supporting a conclusion that the currently available evidence indicates that iAs likely causes fetal, newborn, and infant health outcomes in humans.

A systematic literature search identified 104 epidemiological studies that evaluated the association between exposure to inorganic arsenic (iAs) and fetal, newborn, and infant health outcomes. Citations of studies broken down by confidence level, type of outcome, and studies identified in the 2022 literature update can be accessed via the interactive HAWC literature tag-tree visual presented in Figure 3-27.

These publications underwent study evaluation, and 69 studies were considered medium or high confidence while 23 were considered low or uninformative. Twelve studies identified in the 2022 update were not considered further due to lack of hazard or dose-response utility (see Section 1.6.1). This section focuses on the medium and high confidence studies. The study evaluations of the epidemiologic studies are summarized in HAWC (https://hawc.epa.gov/summary/assessment/100500243/visuals/).

Figure 3-27 Literature tree of epidemiological studies assessing fetal, newborn, and infant health outcomes (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Pregnancy-and-Birth-Outcomes/))

This section presents a review of the evidence for an association between iAs exposure and fetal, newborn, and infant health effects over a range of environmental concentrations in Bangladesh, India, China, the United States, and other countries. Specific outcomes characterized in this section include fetal and infant loss (stillbirth and spontaneous abortion), fetal growth (e.g., head and chest circumference measured in utero or at time of birth), prematurity, birth weight, and growth (e.g., height-for-age, weight-for-age) in the first 10 years of life.^21^ The strongest evidence characterizing the relationship between iAs exposure and fetal loss, infant mortality, prematurity, and other birth outcomes from prospective and cross-sectional studies conducted in Bangladesh and India, where iAs levels in drinking water wells commonly exceeded 200 μg/L. It should be noted that many of these cross-sectional studies included populations that had been highly exposed to arsenic for more than 5−10 years [e.g., (Ahmad et al., 2001; Milton et al., 2005)], which provides increased confidence with regard to temporality compared with typical cross-sectional study scenarios. Ecological studies (with long well-defined exposure periods, limited population migration, large sample sizes, and use of extensive group-level covariates in the analysis) also provide evidence to support an association between iAs exposure >100 μg/L and fetal and infant mortality. There is also evidence for iAs-associated effects at lower levels of arsenic exposure (e.g., <50 μg/L in drinking water) from cohort and cross-sectional studies on fetal, newborn, and infant health outcomes in the United States, Chile, and China [e.g., (Wang et al., 2022a; Mcdermott et al., 2014; Hopenhayn et al., 2003; Claus Henn et al., 2016; Almberg et al., 2017)].

Finally, this section summarizes mechanistic observations and also discusses how an association between iAs and fetal, newborn, and infant health outcomes might be influenced by potential risk modifiers (e.g., polymorphisms, nutrition, methylation capacity, sex).

#### Evidence from Epidemiological Studies

This section summarizes the epidemiological studies that evaluated an association between iAs exposure and fetal or infant mortality, fetal growth, prematurity, birth weight, or postnatal growth. Investigators assessed arsenic exposure by measuring levels in drinking water, air, and soil or by using internal biomarkers (e.g., maternal and cord blood, hair, urine, nails). Each of these exposure approaches has strengths and weaknesses that should be considered in the interpretation of the results, as discussed further in Section 1.6.2.

##### Fetal and infant mortality

The literature review identified 13 medium or high confidence epidemiological studies that evaluated the association between iAs exposure and fetal and infant mortality (von Ehrenstein et al., 2006; Shih et al., 2017; Rahman et al., 2007; Rahman et al., 2010; Nyanza et al., 2020; Myers et al., 2010; Milton et al., 2005; Louis et al., 2017; Kwok et al., 2006; Cherry et al., 2008; Cherry et al., 2010; Bloom et al., 2014; Ahmad et al., 2001) (see Figure 3-27). The most commonly assessed outcomes in these studies were spontaneous abortion, stillbirth, neonatal death (death that occurred in the first month of life), infant death (death in the first year of life), and post-neonatal death (death that occurred between 1 month and 12 months of life). Studies that reported these effect estimates are summarized in Figure 3-29 and Figure 3-30.

Figure 3-28 Study evaluation ratings for references evaluating fetal and infant mortality (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Fetal-and-infant-mortality/))

The strongest evidence for an association between iAs exposure and fetal and infant mortality comes from cohort and cross-sectional studies conducted in Bangladesh (Ahmad et al., 2001; Milton et al., 2005; Rahman et al., 2007; Rahman et al., 2010; Shih et al., 2017) and India (von Ehrenstein et al., 2006), where iAs levels in drinking water wells commonly exceed 200 μg/L. Most of these studies reported positive associations between high iAs levels in drinking water (100 μg/L to >2,000 μg/L) and spontaneous abortion, stillbirth, or neonatal mortality. Many of these studies estimated maternal arsenic exposure using iAs levels from the mother’s primary drinking water source during pregnancy.

A prospective cohort study in Bangladesh by Rahman et al. (2007) assigned arsenic exposure to 29,134 pregnancies based on iAs levels in well water measured at the time of pregnancy. The authors reported a statistically significant, dose-dependent association between iAs drinking water levels 277–408 μg/L and infant mortality, post-neonatal mortality, and fetal loss (a combination of spontaneous abortion and stillbirth) (see Figure 3-29 and Figure 3-30). They did not observe an association between neonatal mortality at any level of arsenic exposure (Rahman et al., 2007). Another prospective cohort study used the same study population and estimated arsenic exposure using total urinary arsenic concentrations collected from 1,725 pregnant women at gestational week 8 (GW 8) and GW 30 (Rahman et al., 2010). That study found a statistically significant association between total urinary arsenic levels and infant mortality in the highest arsenic exposure group (268–2,019 μg/L) (see Figure 3-30). The authors of this study also identified an association between urinary arsenic levels and increased stillbirths and spontaneous abortions, but these associations did not reach statistical significance. The authors comment that both of these endpoints might be affected by exposure or outcome misclassification, resulting in a dilution of the odds ratio and resulting non-significance (Rahman et al., 2010). Shih et al. (2017) analyzed a cohort of highly exposed women with manifest arsenical skin lesions nested within a larger clinical trial and observed increases in infant mortality and fetal loss (stillbirth or spontaneous abortion) associated with creatinine-adjusted urinary total arsenic concentrations above the median level (i.e., 555 μg/g creatinine) (see Figure 3-29). They also reported smaller positive associations when creatinine-adjusted urinary total arsenic concentrations were evaluated on a continuous scale (i.e., per 50 μg/g creatinine increase). Louis et al. (2017) followed 501 couples from Michigan and Texas intending to become pregnant in a prospective cohort study. Of the 344 couples that confirmed a pregnancy, urinary arsenic concentrations (mean = 9.12–11.45 μg/g) from neither the female nor the male partner were associated with pregnancy loss.

An additional prospective cohort study evaluated associations between prenatal maternal arsenic and birth outcomes in communities with and without artisanal and small-scale gold mining (ASGM) in Tanzania (Nyanza et al., 2020). In communities with ASGM, the authors observed that increased total urinary arsenic obtained via maternal urine sample during the second trimester of pregnancy (median (IQR) = 9.6 (5.1–15.9) μg/L) was associated with a statistically significant increased risk of spontaneous abortion and stillbirth (see Figure 3-29).

In a cross-sectional study conducted in Bangladesh, Milton et al. (2005) used a single well water measurement from village tube wells to estimate iAs exposure during pregnancy among a group of mothers. The authors reported a strong, statistically significant association between drinking water iAs levels >50 μg/L (measured after pregnancy) and neonatal mortality, spontaneous abortion, and stillbirth (see Figure 3-29). Similarly, von Ehrenstein et al. (2006) conducted a cross-sectional study in India and measured iAs levels in the village tube wells that mothers had used for at least 6 months after their first pregnancies. They reported a statistically significant increase in stillbirths in the highest (≥200 μg/L) iAs exposure category and a nonsignificant, positive association between arsenic and infant mortality. No association was observed between arsenic exposure and spontaneous abortion (see Figure 3-29). In another cross-sectional study, Kwok et al. (2006) observed no association between iAs drinking water levels (exposure categories ranging from 0 to >300 μg/L) and stillbirth in Bangladesh. Fetal death due to arsenic exposure could have been underestimated because the authors noted that these women typically did not receive early prenatal care.

Figure 3-29 Thumbnail schematic of epidemiological studies addressing the association between inorganic arsenic exposure and stillbirth, fetal loss, and spontaneous abortion (a) ratio measures, urine, continuous exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Fetal-and-Infant-Mortality-Stillbirth-Fetal-L-cont/); (b) ratio measures, drinking water, continuous exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Fetal-and-Infant-Mortality-Stillbirth-Fetal-nonlog/); (c) ratio measures, urine, categorical exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Fetal-and-Infant-Mortality-Stillbirth-Fetal-L-79f1/); (d) ratio measures, drinking water, categorical exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/1c-Fetal-Infant-Mortality-Stillbirth-Fetal-Loss/)

(a) fetal mortality, ratio measures, urine, continuous exposure

(b) fetal mortality, ratio measures, drinking water, continuous exposure

(c) fetal mortality, ratio measures, urine, categorical exposure

(d) fetal mortality, ratio measures, drinking water, categorical exposure

The systematic literature review also identified one case-control study. This study, conducted in Romania by Bloom et al. (2014) observed no association between arsenic and spontaneous pregnancy loss based on estimated iAs exposure from residential drinking water.

Ecological studies also were identified and reviewed. All ecological studies of medium confidence reviewed (with long well-defined exposure periods, limited population migration, large sample sizes, and use of extensive covariates in the analysis) reported a positive association between arsenic exposure in drinking water (up to 860 μg/L) and some measure of infant mortality. Three ecological studies, two conducted in Bangladesh (Cherry et al., 2008; Cherry et al., 2010) and one from China (Myers et al., 2010), used county-level data on iAs levels in drinking water to estimate maternal arsenic exposure (see Figure 3-29 and Figure 3-30). At iAs drinking water levels >50 μg/L, Cherry et al. (2008) and Myers et al. (2010) reported statistically significant associations between stillbirth and neonatal mortality, respectively. Cherry et al. (2010) found a nonsignificant, dose-dependent increase in neonatal/infant mortality within the first year of life.

###### Summary

Across varying geographic regions (e.g., China, Bangladesh, India, Tanzania), study designs (e.g., cross-sectional, cohort, ecological), and outcome metrics (e.g., spontaneous abortion, stillbirth, infant death, neonatal death, and post-neonatal death) there is general consistency in the association between arsenic exposure and fetal and infant mortality from medium and high confidence studies. The strongest evidence is from areas with the highest exposure levels (e.g., >200 μg/L arsenic in drinking water), but there also effects observed at lower exposure levels (e.g., <100 μg/L arsenic in drinking water). A dose-response gradient was observed within some [e.g., (Cherry et al., 2008; Cherry et al., 2010)] but not all studies. Some other studies suggested possible dose-response gradients, but these were attenuated at higher exposure levels [e.g., (Rahman et al., 2007; Rahman et al., 2010; Milton et al., 2005)]. There is also some evidence of a dose-response gradient across studies based on stronger effects from higher exposure regions [e.g., (Shih et al., 2017)] compared with lower exposure regions (Louis et al., 2017). There is some imprecision in the observed results, as some studies have large confidence intervals that include the null.

Figure 3-30 Thumbnail schematic of epidemiological studies addressing the association between inorganic arsenic exposure and infant/neonatal death: ratio measures, drinking water, categorical exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/1a_Fetal-and-Infant-Mortality-InfantNeonatal-Death/) (see interactive data graphic)

(a) Infant mortality, ratio measures, drinking water, categorical exposure

##### Birth weight

The systematic literature review identified 37 medium or high confidence epidemiological studies that evaluated the relationship between iAs and birth weight (see Figure 3-31). Most studies demonstrated inverse associations between arsenic exposure and birth weight using a variety of exposure assessment methods and across diverse geographic areas with a range of exposure levels, though not all were statistically significant (see Figure 3-32). It should be noted that gestational age (discussed below in the section, Prematurity) may be considered a mediator in the relationship between arsenic and birth weight (see Section 1.6.2). Studies discussed in this hazard section may have considered gestational age as a mediator or a confounder in their analyses. Converging findings using these varying approaches to adjustment provide more confidence in the overall conclusions and indicate a logical coherence in the evidence base.

Figure 3-31 Thumbnail schematic of study evaluation ratings for references evaluating birth weight (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Birth-weight/))

Twenty-seven cohort and case-control studies conducted across various geographic regions provide the highest-quality evidence of the relationship between iAs exposure and changes in birth weight (Wai et al., 2017; Thomas et al., 2015; Sun et al., 2019; Signes-Pastor et al., 2019a; Shih et al., 2020; Rahman et al., 2009; Rahman et al., 2017b; Rahman et al., 2021; Nyanza et al., 2020; Mullin et al., 2019; Mcdermott et al., 2014; Liu et al., 2018; Liao et al., 2018; Kim et al., 2020; Kile et al., 2016; Huyck et al., 2007; Hopenhayn et al., 2003; Govarts et al., 2016; Goodrich et al., 2019; Gilbert-Diamond et al., 2016; Freire et al., 2019; Fano-Sizgorich et al., 2021; Daniali et al., 2023; Bulka et al., 2022; Bloom et al., 2015; Bloom et al., 2016; Almberg et al., 2017).

Nineteen of these studies observed inverse associations with birth weight, though not all effect estimates were statistically significant and some estimates were only significant in certain strata (Sun et al., 2019; Rahman et al., 2009; Rahman et al., 2017b; Rahman et al., 2021; Nyanza et al., 2020; Mullin et al., 2019; Mcdermott et al., 2014; Liu et al., 2018; Liao et al., 2018; Kim et al., 2020; Kile et al., 2016; Huyck et al., 2007; Hopenhayn et al., 2003; Govarts et al., 2016; Gilbert-Diamond et al., 2016; Freire et al., 2019; Daniali et al., 2023; Bulka et al., 2022; Bloom et al., 2016; Almberg et al., 2017); (see Figure 3-32). For example, Rahman et al. (2009) measured total urinary arsenic in pregnant mothers from a highly exposed population in Bangladesh at approximately GW 8 and GW 30. The authors observed a statistically significant, inverse association between average maternal urinary arsenic levels (mean (SD) of GW 8 and GW 30 urinary arsenic: 160 (163) μg/L) and birth weight (beta (SE): −1.68 (0.62)). In addition, a small prospective cohort study of 49 subjects in Bangladesh found a statistically significant inverse association between maternal arsenic levels in hair (0.14–3.28 μg/g) at their first prenatal visit (before GW 28) and birth weight (beta (SE): −193.5 (90)) (Huyck et al., 2007). Rahman et al. (2017b) observed inverse associations between concentrations of arsenic in drinking water (median = 2.2 μg/L) and birth weight in a prospective cohort study conducted in Bangladesh, with associations mediated through gestational age as well as based on pathways independent of gestational age. The decreases in birth weight associated with arsenic exposure were greater in magnitude for babies with lower birth weight. For example, for babies with birthweight <2300 g, each unit increase in ln-transformed water arsenic was associated with a 47.7 g decrease (95% CI: −63.1, −29.4) in birthweight, while the results were attenuated for babies with birthweight <2,800 g (−18.7 (−31.3, −5.5)). Results were similar when arsenic measured in toenail samples were used to assign exposure (Rahman et al., 2017b). Kile et al. (2016) measured arsenic in drinking water at the time of enrollment (gestational age <16 weeks) (median: 2.3 μg/L) and in toenails collected ≤1 month postpartum (median: 1.46 μg/g). They observed decreased birth weight for every unit increase in natural log drinking water arsenic (beta (95% CI): −19.17 g (−24.64, −13.69)) and toenail arsenic (beta (95% CI): −15.72 g (−24.52, −6.91)), with associations mediated through gestational age and maternal weight gain during pregnancy.

In Taiwan, Liao et al. (2018) measured arsenic in maternal urine samples from 130 women during each trimester of pregnancy (mean urinary arsenic in each trimester: 40.0–41.8 μg/L) and reported a decrease in estimated birth weight associated with increased arsenic exposure, with strongest and statistically significant effects in the second trimester (beta (95% CI): first trimester: −123.88 g (−258.16, 10.41); second trimester (−173.26 g (−293.56, −52.95); third trimester (−14.51 g (−161.22, 132.20)). Using a similar study design, Liu et al. (2018) measured arsenic in maternal urine samples from 1,390 women in Wuhan, China during each trimester of pregnancy (median SG-adjusted urinary arsenic in each trimester: 20.27–21.86 μg/L). They observed decreases in birth weight associated with third trimester maternal urinary arsenic concentrations (beta (95% CI): −24.27 g (−46.99, −1.55)) but mixed results in earlier trimesters (beta (95% CI): first trimester: −3.89 g (−25.21, 17.42); second trimester (6.79 g (−16.56, 30.13)). In stratified analyses, the significant association in the third trimester persisted for girls (beta (95% CI): −37.66 g (−71.57, −3.75)) but was attenuated for boys (beta (95% CI): −13.57 g (−44.26, 17.13)).

Figure 3-32 Thumbnail schematic of epidemiological studies addressing the association between inorganic arsenic exposure and birth weight (a) birth weight, difference measures, biomarkers, continuous exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/2d_Birth-Weight-Beta_Coeff-cont-rev/); (b) birth weight, difference measures, drinking water, continuous exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Birth-Weight-coeff-cont_water/); (c) birth weight, difference measures, biomarkers, categorical exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/2d_Birth-Weight-Coefficient-categorical/); (d) birth weight, difference measures, drinking water, categorical exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Birth-Weight-Coef-Categorical-drinking-water/); (e) low birth weight, ratio measures, biomarkers, continuous exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Birth-Weight-ratio-measure-biomarkers-continu-509a/); (f) Small for gestational age, ratio measures, biomarkers, categorical exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Fetal-Growth-OR-categorical-biomarker/) (see interactive data graphic)

(a) Birth weight, difference measures, biomarkers, continuous exposure

(b) Birth weight, difference measures, drinking water, continuous exposure

(c) Birth weight, difference measures, biomarkers, categorical exposure

(d) Birth weight, difference measures, drinking water, categorical exposure

(e) Low birth weight – ratio measures – biomarkers – continuous exposure

(f) Small for gestational age – ratio measures – biomarkers -categorical exposure

Hopenhayn et al. (2003) conducted a prospective cohort study in two Chilean towns, Antofagasta, and Valparaiso, with high (30–40 μg/L) or low (<1 μg/L) iAs levels in the drinking water, respectively. Babies born to women living in Antofagasta (high arsenic exposure) had lower average birth weight compared with babies born to women living in Valparaiso (low arsenic exposure) (beta (95% CI): −57 g (−123, 9)). Results were similar but attenuated when using an individual-level measure of exposure (beta (95% CI) per μg arsenic: −0.26 g (−0.85, 0.31)). The authors also found that the association between iAs and birth weight was nearly twice as large in preterm infants (beta (95% CI): −107 g (−265, 50)) compared with full-term infants (beta (95% CI): −44 g (−115, 27)), but the interaction was not statistically significant (Hopenhayn et al., 2003). Bloom et al. (2016) conducted a preliminary cohort study using pregnant women (n = 122) to evaluate low-level arsenic exposure (<10 μg/L) and birth outcomes. Study authors found that exposure to higher average arsenic concentrations (10 μg/L) was associated with lower birth weight z-score among smokers (beta (95% CI): −2.45 (−4.49, −0.42)).

Six cohort studies observed associations with increased birth weight, though most of these effect estimates were not statistically significant (Signes-Pastor et al., 2019a; Shih et al., 2020; Mullin et al., 2019; Goodrich et al., 2019; Fano-Sizgorich et al., 2021; Bloom et al., 2015). For example, in a small (n = 56) cohort based in Michigan with geometric mean maternal urinary arsenic of 4.3 μg/L, Goodrich et al. observed a suggestive positive association with birthweight (beta (95% CI): 9.03 g (−92.34, 110.39)) (Goodrich et al., 2019). Bloom et al. (2015) conducted a prospective cohort study using the LIFE cohort in the United States. They found no association between preconception maternal (mean: 17.13 μg/L) or paternal (mean: 19.65 μg/L) total urinary arsenic levels and birth weight, except for a statistically significant, positive association between the highest tertile of paternal urinary arsenic levels (≥20.15 μg/L) and birth weight (beta (95% CI): 194.71 g (17.13, 372.30)).

Ten cross-sectional studies that evaluated the association between arsenic and birth weight also were identified in the literature search (Xu et al., 2022; Wang et al., 2022a; Luo et al., 2017; Laine et al., 2015; Kwok et al., 2006; Hu et al., 2015; Guan et al., 2012; Gelmann et al., 2013; Claus Henn et al., 2016; Bermudez et al., 2015) (see Figure 3-32). Luo et al. (2017) measured As in whole blood samples (median ~ 0.044 μg/dL) collected in the first trimester of pregnancy from 275 women in North Carolina. Moderate arsenic exposure (i.e., maternal whole blood arsenic concentrations between the 33rd and 67th percentiles), but not high arsenic exposure (i.e., >67th percentile) were associated with decreases in birthweight (beta (SE): −366.5 g (175.2)). The decrease in birthweight associated with moderate arsenic exposure was greater in male infants (beta (SE): −870.69 g (372.09)) and nonsmoking mothers (beta (SE): −464.29 g (202.74)). Guan et al. (2012) studied an urban population in China and measured arsenic levels in cord blood and maternal blood at delivery. They reported median arsenic concentrations of 5.30 and 3.71 μg/L in maternal and cord blood, respectively. Guan et al. (2012) observed a statistically significant, inverse association between maternal blood arsenic levels and birth weight beta (p-value): −0.19 kg (0.015)). Two other cross-sectional studies in China evaluating exposure via maternal blood arsenic (median = 5.45 μg/L) and cord blood arsenic (median = 1.71–5.38 μg/L) also reported inverse associations between blood arsenic concentrations and birth weight (cord blood beta (95% CI): −19.39 g (−38.14, −0.63); cord blood beta (95% CI): −0.028 kg (−0.041, −0.016); maternal blood beta (95% CI): −0.027 kg (−0.041, −0.013)) (Xu et al., 2022; Wang et al., 2022a).

However, some cross-sectional studies reported null results or estimates whose confidence intervals included the null. For example, one study conducted in Bangladesh found no association between drinking water iAs levels (median across regions: 24–139 ppb) and odds of low birth weight (OR (95% CI): 0.99 (0.99, 1.00) (Kwok et al., 2006). Similarly, a cross-sectional study conducted in China by Hu et al. (2015) observed a non-statistically significant inverse association between both maternal and cord blood arsenic levels (median = 11.0 and 10.4 ng/g, respectively) and birth weight (maternal blood beta (95% CI): −1.5 g (−20.2, 17.3)); cord blood beta (95% CI): −13.6 (−33.9, 6.7)). Laine et al. (2015) conducted a cross-sectional study in Mexico and estimated arsenic exposure using drinking water iAs levels shortly after birth (mean = 24.6 μg/L) and maternal urinary arsenic levels before birth (mean iAs = 2.1μg/L). They observed a non-statistically significant association with reduced birth weight (drinking water beta (95% CI): −0.1 g (−1.7, 1.4); maternal urine beta (95% CI): −21.7 g (−46.8, 3.4)). In a study conducted in Romania, Gelmann et al. (2013) estimated iAs exposure using both maternal urinary and drinking water iAs levels. Drinking water iAs levels were not significantly different between women who had low-birth-weight babies (56.9 ± 24.7 μg/L) or normal-birth-weight babies (52.2 ± 30.0 μg/L). For these and other “non-significant” findings, it should be noted that even changes that are not statistically significant could be biologically significant and also that changes that are not significant at the individual level could be meaningful at the population level (Gilbert and Weiss, 2006). Among women classified as “exposed” (iAs concentrations in drinking water ≥10 μg/L), however, women who delivered low-birth-weight babies had a significantly higher prevalence of maternal urinary iAs levels >9 μg/L (67%) compared with women with normal-birth-weight outcomes (10%). The authors also found that none of the exposed women with normal-birth-weight infants had a urine iAs concentration ≥10 μg/L and suggested that this might be due to maternal differences in arsenic metabolism (methylation) and excretion (Gelmann et al., 2013).

###### Summary

High and medium confidence studies across diverse geographic regions (e.g., China, United States, Chile, Bangladesh) representing a range of exposure levels and utilizing a variety of exposure assessment methods provide generally consistent results indicating statistically significant and nonsignificant inverse associations between iAs and birth weight. This association may be mediated by gestational age (see Section on Prematurity, below). There is some evidence for a dose-response gradient, though the gradient was attenuated at higher levels [e.g., (Wang et al., 2022a)]. There is some imprecision in the observed results, as some studies have large confidence intervals that include the null.

##### Fetal growth

Eighteen medium or high confidence epidemiological studies were identified that measured indices of fetal growth in utero or at birth (see Figure 3-33). Approximately half of these studies used total urinary maternal arsenic levels to estimate exposure (Sun et al., 2019; Shih et al., 2020; Louis et al., 2017; Liu et al., 2018; Liao et al., 2018; Kippler et al., 2012; Kim et al., 2020; Goodrich et al., 2019; Fano-Sizgorich et al., 2021; Davis et al., 2015).

There were 12 cohort or case-control studies evaluating the association between arsenic and fetal growth measures (Sun et al., 2019; Signes-Pastor et al., 2019a; Shih et al., 2020; Röllin et al., 2016; Rahman et al., 2021; Liu et al., 2018; Liao et al., 2018; Kim et al., 2020; Goodrich et al., 2019; Freire et al., 2019; Fano-Sizgorich et al., 2021; Daniali et al., 2023). Cohort studies conducted in Taiwan (Liao et al., 2018)and Wuhan, China (Liu et al., 2018) observed statistically significant associations between maternal urinary arsenic and impaired fetal growth (see Figure 3-33). Liao et al. (2018) measured arsenic in maternal urine samples from 130 women during each trimester of pregnancy (geometric mean by trimester: first trimester = 41.8 μg/L; second trimester = 40.0 μg/L; third trimester = 40.6 μg/L) and reported a statistically significant decrease in head circumference birth in association with increased second trimester maternal arsenic exposure (beta (95% CI): −0.61 cm (−1.07, −0.15)). They also observed a significant decrease in chest circumference in association with increased first and second trimester maternal urinary arsenic (first trimester beta (95% CI): −0.72 cm (−1.32, −0.12); second trimester beta (95% CI): −0.65 cm (−1.20, −0.11)) as well a significant decrease in biparietal diameter in relation to urinary arsenic over all three trimesters (beta (95% CI): −1.05 mm (−1.95, −0.15)). Liu et al. (2018) measured arsenic in maternal urine samples from 1,390 women during each trimester of pregnancy. They observed decreases in birth length associated with arsenic concentrations measured in maternal urine during the third trimester of pregnancy (median = 13.59 μg/L; beta (95% CI): −0.13 cm (−0.22, −0.04)). In stratified analyses, these associations persisted for girls (beta (95% CI): −0.18 cm (−0.31, −0.05)), but were attenuated for boys (beta (95% CI): −0.09 (−0.21, 0.03)) (see Figure 3-33). However, another study in China observed suggestive but null effects of second trimester maternal urinary arsenic (geometric mean = 20.03 μg/L) on birth length (beta (95% CI): −0.13 cm (−0.28, 0.03)) (Sun et al., 2019).

There were also nine cohort or case-control studies based in North America, with mixed findings. Two studies observed statistically significant inverse associations between maternal arsenic (geometric mean urinary arsenic = 4.3 μg/L; median toenail arsenic = 0.05 μg/g) and fetal growth parameters: femur length [beta (95% CI): −0.26 mm (−0.46, −0.07)] (Goodrich et al., 2019); head circumference (males only) [beta (95% CI): −0.20 cm (−0.38, −0.02)] (Signes-Pastor et al., 2019a). Three studies observed statistically significant positive associations between maternal urinary arsenic during pregnancy (median = 3.96–7.7 μg/L) and fetal growth parameters: birth length [beta (95% CI): 0.28 cm (0.14, 0.42) (Shih et al., 2020); 0.22 cm (0.01, 0.44) (Signes-Pastor et al., 2019a)]; head circumference [beta (95% CI): 0.12 (0.04, 0.21)(Shih et al., 2020)]. Two studies documented no association with fetal growth parameters (Rahman et al., 2021; Kim et al., 2020).

Studies in other parts of the world (Spain, Peru, and Iran) did not observe any statistically significant associations with fetal growth parameters when assessing arsenic via urine (geometric mean total urinary arsenic = 43.97 μg/L), placenta (median <0.004 ng/g), or blood (geometric mean = 2.21 μg/L) (Freire et al., 2019; Fano-Sizgorich et al., 2021; Daniali et al., 2023).

Six cross-sectional studies were also identified (Xu et al., 2022; Wang et al., 2022a; Lee et al., 2021; Kippler et al., 2012; Davis et al., 2015; Claus Henn et al., 2016). Four of these studies evaluated fetal growth endpoints at birth in relation to maternal or cord blood (Xu et al., 2022;Wang et al., 2022a; Lee et al., 2021; Claus Henn et al., 2016). Mixed findings were observed (see Figure 3-34). One study in China did not observe associations between cord blood arsenic (median (IQR) = 1.71 (2.03) μg/L) and birth length (beta (95% CI): 0.01 cm (−0.01, 0.21)) or head circumference (beta (95% CI): 0.01 cm (−0.03, 0.06)) (Wang et al., 2022a), while another study in China observed inverse associations for both birth length and head circumference in relation to maternal blood arsenic (median (range) = 5.45 (0.7–17.1) μg/L; beta (95% CI): birth length: −0.12 cm (−0.18, −0.06); head circumference: −0.05 cm (−0.09, −0.01)). Results were similar for cord blood arsenic (median (range) = 5.38 (0.7–23.6) μg/L) (Xu et al., 2022). In a population in the U.S. living near a mining-related Superfund site, maternal blood arsenic (median (IQR) = 1.4 (0.97–2.3) μg/L) – but not cord blood arsenic (median (IQR) = 2.4 (1.8–3.3) μg/L) – was associated with decreased head circumference (beta (95% CI): −0.22 cm (−0.42, −0.03)) (Claus Henn et al., 2016). The remaining two cross-sectional studies evaluated exposure via maternal urinary samples and evaluated fetal growth during gestation (Kippler et al., 2012; Davis et al., 2015). In a study based in Bangladesh, Kippler et al. (2012) measured total urinary arsenic concentrations in mothers at GW 8 (median = 79 μg/L) and GW 30 (median = 85 μg/L) and evaluated five endpoints of fetal size by ultrasound at GW 14 and GW 30, including three fetal head measurements (head circumference, biparietal diameter, occipitofrontal diameter), abdominal circumference, and femur length. At GW 14, the authors observed a statistically significant, inverse association between maternal urinary arsenic levels at GW 8 and occipitofrontal diameter z-score (beta (95% CI): −0.06 (−0.11, −0.008)). At GW 30, a statistically significant association was found between decreased femur length z-score and maternal urinary arsenic levels at GW 30 (beta (95% CI): −0.04 (−0.07, −0.005)). No association was found between other fetal growth endpoints and maternal arsenic at either GW 14 or GW 30. When the data were stratified by sex, authors reported a weak inverse association between maternal arsenic levels (GW 8 and GW 30) and femur length, head circumference, and occipitofrontal diameter in males at GW 14 and GW 30 but not in females (Kippler et al., 2012). In a study based in New Hampshire, maternal urinary arsenic (median (IQR) = 3.1 (1.5–5.5) μg/L) was not associated with fetal growth at 18–22 weeks (e.g., head circumference beta (95% CI): −0.02 mm (−0.05, 0.01)) (Davis et al., 2015).

###### Summary

High and medium confidence studies covering a range of exposure levels across diverse geographic regions (e.g., United States, China, Bangladesh) and evaluating varying fetal growth outcomes suggest unexplained inconsistency regarding the effect of arsenic on fetal growth. Some studies provide evidence of inverse associations, others provide evidence of positive associations, and others are null. Inverse associations are observed in regions with both high (e.g., Bangladesh, China) and low (e.g., United States) arsenic exposure. There is some imprecision in the observed results, as some studies have large confidence intervals that include the null.

Figure 3-33 Study evaluation ratings for references evaluating fetal growth (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Fetal-growth/))

Figure 3-34 Thumbnail schematic of epidemiological studies addressing the association between inorganic arsenic exposure and fetal growth (a) measures of length – difference measures, biomarkers, continuous exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Fetal-Growth-coefficient/); (b) measures of length, difference measures, biomarkers, categorical exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Fetal-Growth-coefficient_quartiles/); (c) head growth, difference measures, biomarkers, continuous exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Fetal-Growth-coefficient_head/); (d) head growth, difference measures, biomarkers, categorical exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Fetal-Growth-coefficient_head_quartiles/) (see interactive data graphic)

(a) Measures of length, difference measures, biomarkers, continuous exposures

(b) Measures of length, difference measures, biomarkers, categorical exposures

(c) Head growth, difference measures, biomarkers, continuous exposures

(d) Head growth, difference measures, biomarkers, categorical exposures

##### Prematurity

Eighteen medium or high confidence studies were identified that assessed the association between iAs and preterm birth (defined in most studies as birth prior to GW 37) and/or continuous measures of gestational age (see Figure 3-35 and Figure 3-36) (Yu et al., 2019; Wai et al., 2017; Shih et al., 2020; Röllin et al., 2016; Rahman et al., 2017a; Rahman et al., 2021; Nyanza et al., 2020; Myers et al., 2010; Laine et al., 2015; Karakis et al., 2021; Howe et al., 2020; Freire et al., 2019; Fano-Sizgorich et al., 2021; Bulka et al., 2022; Bloom et al., 2015; Almberg et al., 2017; Ahmad et al., 2001; Aelion et al., 2012). Most of these studies, from the United States, Spain, China, Israel, Peru, and Myanmar, observed no association between arsenic and preterm birth (see Figure 3-36) (Yu et al., 2019; Wai et al., 2017; Shih et al., 2020; Rahman et al., 2021; Myers et al., 2010; Karakis et al., 2021; Howe et al., 2020; Freire et al., 2019; Fano-Sizgorich et al., 2021; Bulka et al., 2022; Bloom et al., 2015). For example, a prospective cohort study by Bloom et al. (2015) analyzed couples enrolled in the Longitudinal Investigation of Fertility and the Environment (LIFE) in the United States and found no association between prepregnancy maternal total urinary arsenic levels (mean (SD) = 17.13 (28.76) μg/L) and gestational age at delivery (beta (95% CI): 2nd tertile vs. ref: −0.40 (−1.43, 0.63); 3rd tertile vs ref: −0.02 (−1.17, 1.13)). Wai et al. (2017) evaluated the association between creatinine-adjusted urinary total arsenic (mean = 74.2 μg/g) measured during the third trimester in 419 women in Myanmar and observed a null association with preterm birth. (OR (95% CI): 1.0 (0.99–1.0))

Figure 3-35 Study evaluation ratings for references evaluating prematurity (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Prematurity/))

Conversely, seven studies (Röllin et al., 2016; Rahman et al., 2017a; Nyanza et al., 2020; Laine et al., 2015; Almberg et al., 2017; Ahmad et al., 2001; Aelion et al., 2012) observed associations with preterm birth using a variety of exposure assessment metrics and across a variety of geographic areas (see Figure 3-36). Two studies conducted in South Africa reported associations with preterm birth at varying exposure levels: Ahmad et al. (2001) observed positive associations with drinking water levels >50 μg/L in a cross-sectional analysis, while a cohort study conducted by Rahman et al. (2017a) reported a positive association with drinking water at much lower levels (median = 2.2 μg/L; RR (95% CI): 1.12 (1.07, 1.18)); results were similar when arsenic measured in toenail samples (median = 1.2 μg/g; RR (95% CI): 1.13 (1.03, 1.24)) was used to assign exposure. In a cohort study based in South Africa, Röllin et al. (2016) reported an inverse association between maternal blood arsenic levels at delivery (geometric mean = 0.96 μg/L) and gestational age (beta (95% CI): −0.054 (−0.087, −0.020)). Finally, a cross-sectional study conducted in Mexico observed an association between urinary iAs levels (mean = 2.1 μg/L) and gestational age at delivery (beta (95% CI): −0.069 weeks (−0.13, −0.0043)) (Laine et al., 2015).

###### Summary

Most studies, covering varying geographic regions, reported no association between arsenic exposure and prematurity. However, seven studies presenting both higher and lower exposure scenarios reported positive associations between arsenic exposure and preterm birth. There is unexplained inconsistency is this set of medium and high confidence studies. There is some evidence of a dose-response gradient across studies, with some stronger effects documented in areas with higher arsenic exposures [e.g., (Rahman et al., 2017a)] compared with lower arsenic exposures [e.g., (Almberg et al., 2017)]. There is some imprecision in the observed results, as some studies have large confidence intervals that include the null.

Figure 3-36 Thumbnail schematic of epidemiological studies addressing the association between inorganic arsenic exposure and prematurity (a) gestational age, difference measures, biomarkers, continuous exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/2e_gestationalage-coeff/); (b) gestational age, difference measures, biomarkers, categorical exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Gestational-Age-Coefficient-categorical/); (c) preterm birth, ratio measures, biomarkers, continuous exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Prematurity-ORRR/); (d) preterm birth, ratio measures, drinking water, continuous exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Prematurity-ORRR-cont-water/) (see interactive data graphic)

(a) Gestational age, difference measures, biomarkers, continuous exposures

(b) Gestational age, difference measures, biomarkers, categorical exposures

(c) Preterm birth, ratio measures, biomarkers, continuous exposures

(d) Preterm birth, ratio measures, drinking water, continuous exposures

##### Postnatal growth

The evidence for an association between pregnancy iAs exposure and postnatal growth effects is limited to six medium or high confidence prospective cohort studies (see Figure 3-37), four of which were conducted in Bangladesh (Wai et al., 2020; Saha et al., 2012; Malin Igra et al., 2021; Gardner et al., 2013). The other two studies were conducted in New Hampshire (Muse et al., 2020) and Israel (Karakis et al., 2021).

Two of these studies suggest that prenatal arsenic exposure at a range of concentrations can affect postnatal growth (see Figure 3-38). Wai et al. (2020) observed an inverse association between maternal second or third trimester total urinary arsenic (geometric mean = 50.8 μg/L) and head circumference for age z-score at 1–6 months of age (beta (95% CI): −1.20 (−1.97, −0.42)). By contrast, Muse et al. (2020) documented a positive association between maternal second trimester total urinary arsenic (median = 3.96 μg/L) and length z-score over the first year of life (beta (95% CI): 0.05 (0.00, 0.09)) but an inverse association with length growth rate up to 3.5 months (beta (95% CI): −0.07 cm/mo (−0.12, −0.02). Other studies observed no significant associations between prenatal arsenic exposures at a range of concentrations (median maternal blood arsenic = 4.3 μg/kg; maternal central tendency urinary arsenic = 3.59 μg/L – 80–84 μg/L) and childhood growth outcomes up to age 10 years (Saha et al., 2012; Malin Igra et al., 2021; Karakis et al., 2021; Gardner et al., 2013).

###### Summary

From a limited evidence base of medium or high confidence studies, two studies (one in Bangladesh, one in USA) document changes in postnatal growth in relation to prenatal exposure but four studies at overlapping exposure levels document no significant associations. There is unexplained inconsistency in this small evidence base. There is coherence with the evidence for birth weight and some of the evidence for fetal growth. There is some imprecision in the observed results, as some studies have large confidence intervals that include the null.

Figure 3-37 Study evaluation ratings for references evaluating postnatal growth (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Postnatal-growth/))

Figure 3-38 Thumbnail schematic of epidemiological studies addressing the association between inorganic arsenic exposure and postnatal growth (a) measures of length, difference measures, biomarkers, continuous exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/2f_Postnatal-Growth/); (b) measure of length, difference measure, biomarkers, categorical exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Postnatal-Growth-Coefficient-length-parameter-a751/); (c) measures of weight, difference measures, biomarkers, continuous exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Postnatal-Growth-Coefficient-weight-parameter-07b4/); (d) measures of weight, difference measure, biomarkers, categorical exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Postnatal-Growth-Coefficient-weight-parameter-9f7b/) (see interactive data graphic)

(a) Measures of length, difference measures, biomarkers, continuous exposure

(b) Measure of length, difference measure, biomarkers, categorical exposure

(c) Measures of weight, difference measures, biomarkers, continuous exposure

(d) Measures of weight, difference measures, biomarkers, continuous exposure

#### Mechanistic Observations and Biological Plausibility

Arsenic exposure could affect fetal or infant development by damaging the fetus directly or by impairing the function of the placenta and thereby negatively affecting fetal growth and development. Whether maternal iAs is taken up by the placenta (Hanlon and Ferm, 1987) and the fetus (Hood et al., 1988; Gerber et al., 1982) is unclear. Human studies, such as that by Huyck et al. (2007) demonstrated uptake of arsenic by the fetus. A few studies have evaluated the mechanism of arsenic on the placenta. Using a human extravillous trophoblast cell line, Li and Loch-Caruso (2007) found that placental trophoblast migration is reduced by arsenic, an effect that could cause poor placental development. Two studies by the same group showed that arsenic impaired vasculogenesis of the placenta in pregnant mice, which could reduce nutritional uptake by the fetus and lead to reduced birth weight (Coffin et al., 2006; He et al., 2007). Remy et al. (2014) found that arsenic was associated with upregulation of soluble fms-like tyrosine kinase-1 (sFLT1), a protein that inhibits placental angiogenesis, in human female cord blood. The authors of this study also found a correlation between arsenic exposure and increased expression of genes related to DNA damage and oxidative stress in cord blood, (e.g., GPX7, SNCA, YBX1, BRCA1, MMP2, MMP9, PEMT, S100A12, SELK, TAT, VNN1and MYC)but found no association between these effects and fetal, newborn, and infant health outcomes. Fei et al. (2013) found that maternal arsenic exposure in humans was correlated with placental upregulation of aquaporin 9 (AQP9), which encodes a membrane transporter that contributes to arsenic uptake. A related decrease in ENPP2 was associated with decrease in birth weight.

Studies using human placentas or placental cell lines suggest that arsenic might increase oxidative stress and cytokine expression, including increased intracellular H_2_O_2_ (Massrieh et al., 2006) and increased expression of TNFα and IFN-γ (Ahmed et al., 2011). Oxidative stress is an established mode of action for arsenic and is described in detail in Appendix A of the iAs Protocol. Another study showed that arsenic exposure causes increases in TNF-related inflammatory proteins in cord blood (Bailey et al., 2014). As a whole, the studies described here suggest a variety of pathways by which arsenic exposure could affect the placenta in ways that reduce fetal growth and lead to low birth weight.

In addition, researchers have identified direct effects of arsenic on mouse embryonic cells that plausibly could lead to reduced fetal growth. Arsenic treatment of mouse embryonic cells induced oxidative stress (Ren et al., 2014; Singh et al., 2010; Zhang et al., 2010), cell death, and DNA damage (Mirkes and Little, 1998). That these inflammatory and oxidative stress effects impair the ability of the fetus and infant to thrive is plausible. Specific pathways by which arsenic-induced stress and DNA damage could affect prenatal and postnatal growth are not clear.

Because iAs metabolism appears to increase in humans in late pregnancy and arsenic is not passed readily through breast milk, arsenic exposure during the perinatal period might not be associated with infant death via direct toxic mechanisms (Fängström et al., 2008; Concha et al., 1998). In a prospective cohort study in Bangladesh, Rahman et al. (2011) found increased risk of diarrhea, lower respiratory tract infections, and severe lower respiratory tract infections (maternal reports) among infants born to mothers in the highest quintiles of urinary arsenic concentration (>261 μg/L) in pregnancy compared with those with low urinary arsenic (<261 μg/L). In a study in the United States (New Hampshire), Farzan et al. (2013b) also found increased risk of infections (diarrhea, lower respiratory tract) in infants born to mothers with higher urinary arsenic. Although actual infant deaths from diarrhea or respiratory infections are comparatively uncommon in the United States, they are major causes of infant mortality worldwide (Liu-Mares et al., 2013). There is ample evidence that generation of reactive oxygen species (ROS) and oxidative stress are MOAs involved in arsenic toxicity as there is no one “established” MOA for iAs. For more information see Appendix A of the iAs protocol).

Inorganic arsenic exposure may affect fetal or infant development by damaging the fetus directly or indirectly by impairing placental function and thereby negatively affecting fetal growth and development. Human fetal arsenic uptake has been evaluated, as an example (Huyck et al., 2007) showed that increased arsenic measured in maternal hair negatively correlated with birth weight in a Bangladeshi population exposed to > 50 μg/L arsenic in drinking water. Li et al., (2007) showed a dose-dependent decrease in placental trophoblast migration in response to 0, 0.625, 1.25, or 2.5 μM arsenic. Decreases in placental trophoblast migration could result in poor placental development. Arsenic has also been found to inhibit placental angiogenesis (Remy et al., 2014). Maternal arsenic exposure in humans is correlated with placental upregulation of aquaporin 9 (AQP9), which encodes a membrane transporter that contributes to arsenic uptake. A related decrease in ENPP2, which stimulates angiogenesis, was associated with decrease in birth weight (Fei et al., 2013).

Evidence in rodent studies support the epidemiological observations of a correlation between arsenic exposure and low birth weight; as an example, pregnant mice exposed to arsenic experienced impaired placental vasculogenesis, which could reduce nutritional uptake by the fetus and lead to reduced birth weight (Coffin et al., 2006; He et al., 2007). In addition, researchers have identified direct effects of arsenic on mouse embryonic cells that plausibly could lead to reduced fetal growth. Arsenic treatment of mouse embryonic cells induced oxidative stress (Ren et al., 2014; Singh et al., 2010; Zhang et al., 2010), cell death, and DNA damage (Mirkes and Little, 1998). That these inflammatory and oxidative stress effects impair the ability of the fetus and infant to thrive is plausible. The above studies provide evidence of biologically plausible pathways by which arsenic exposure could affect the placenta in ways that would result in reduced fetal growth and lead to low birth weight.

#### Risk Modifiers

A review of the epidemiological studies discussed in this section, along with studies identified from a targeted literature search (see Section 3.10 of iAs Protocol), suggest the following as potential modifying factors that may affect the risk of arsenic-associated adverse fetal, newborn, and infant health outcomes (see Table 3-6). (Note that this section is not a comprehensive list of risk modifiers but rather provides selected examples):

- Sex: Information is inconclusive regarding whether males or females are more susceptible to arsenic-induced morbidity or mortality during pregnancy. Some studies suggest increased susceptibility among males for certain outcomes (Signes-Pastor et al., 2019a; Luo et al., 2017; Kippler et al., 2012), while others suggest increased susceptibility among females for other outcomes (Signes-Pastor et al., 2019a; Liu et al., 2018).
- Nutritional status: Some evidence suggests that the impact of arsenic on infant birth weight is stronger among women who are B12 deficient or who have hyperhomocysteinemia (Clark et al., 2022).
- Smoking: Some evidence suggests that the impact of arsenic on birth weight and birth weight is stronger among smokers (Bloom et al., 2016).
- Maternal prepregnancy weight: Some evidence suggests that the impact of arsenic on birth weight and fetal growth parameters is stronger for women who are overweight/obese (Gilbert-Diamond et al., 2016).

Table 3-6 Risk modifiers for fetal, newborn, and infant health outcomes (selected study examples)

Risk modifiers | References | Finding | Population, exposure level
Sex | Kippler et al. (2012) | Stronger associations with fetal size among males | Bangladesh, 168 μg/L (prenatal mean maternal urine)
| Luo et al. (2017) | Stronger associations with birth weight among males | United States, ~0.4 μg/L (prenatal median maternal blood)
| Liu et al. (2018) | Stronger associations with birth weight and birth length in females | China, 20–21 μg/L (prenatal median maternal SG-adjusted urine)
| Signes-Pastor et al. (2019a) | Stronger associations with birth weight and birth length in females; stronger associations with head circumference among males | United States, 0.05 μg/g (postnatal median maternal toenail)
Nutritional status | Clark et al. (2022) | Stronger associations for birth weight among infants born to women who were B12 deficient or with hyperhomocysteinemia | Mexico, 1.3 μg/L (maternal mean SG-adjusted urinary inorganic arsenic at delivery)
Smoking | Bloom et al. (2016) | Elevated arsenic associated with lower birth weight and shorter birth length among smokers only | Romania, 4.11 μg/L (mean drinking water)
Maternal prepregnancy weight | Gilbert-Diamond et al. (2016) | Elevated arsenic associated with lower ponderal index in infants of overweight/obese mothers. Elevated arsenic associated with lower birth weight among females born to overweight/obese mothers. | United States, 0.3 μg/L (median urinary arsenic)

#### Evidence Judgment

The currently available evidence indicates that iAs exposure likely causes adverse fetal, newborn, and infant health outcomes in humans (see Table 3-7) given sufficient exposure conditions.^22^ This conclusion is based on epidemiological studies at a range of exposure levels (including <100 μg/L, as well as <20 μg/L) demonstrating associations between iAs exposure and increased fetal and infant mortality, changes in fetal and postnatal growth, length of gestation or birth weight across diverse geographic areas. (Supplemental figures of results from studies documenting adverse effects from exposure to inorganic arsenic in drinking water at concentrations less than or equal to 100 μg/L, as described in 1.6.3, are available in Appendix B.5.)

Overall, there is moderate evidence for an association between arsenic exposure and fetal and infant mortality, based on 13 medium or high confidence studies. The strongest evidence supporting an association between iAs exposure and these outcomes is from cohort and cross-sectional studies conducted in Bangladesh and India, where iAs levels in drinking water wells commonly exceeded 200 μg/L [e.g., (Ahmad et al., 2001; Milton et al., 2005; Rahman et al., 2007; Rahman et al., 2010; Shih et al., 2017; von Ehrenstein et al., 2006)]. Ecological studies in Bangladesh and China also provide supporting evidence for the association between iAs exposure and fetal and infant mortality, including at lower levels of exposure (e.g., <100 μg/L in drinking water) (Cherry et al., 2010; Myers et al., 2010; Cherry et al., 2008). Overall, there is general consistency within the evidence base across several study types (cross-sectional, cohort, ecological), geographic regions (China, Bangladesh, India, and Tanzania), and outcome metrics (spontaneous abortion, stillbirth, infant death, neonatal death, and post-neonatal death). A dose-response gradient was observed within some [e.g., (Cherry et al., 2008; Cherry et al., 2010)] but not all studies. Some other studies suggested possible dose-response gradients, but these were attenuated at higher exposure levels [e.g., (Rahman et al., 2007; Rahman et al., 2010; Milton et al., 2005)]. There is also some evidence of a dose-response gradient across studies based on stronger effects from higher exposure regions [e.g., (Shih et al., 2017)] compared with lower exposure regions (Louis et al., 2017).

There is also moderate evidence for an association between arsenic exposure and birth weight. Thirty-five medium or high confidence studies across diverse geographic regions (e.g., China, United States, Chile, Bangladesh) representing a range of exposure levels and utilizing a variety of exposure assessment methods provide general consistency regarding inverse and suggestive inverse associations between iAs and birth weight. This association may be mediated by gestational age (see Section on Prematurity, below). There is coherence with some of the evidence for fetal growth, postnatal growth, and prematurity.

There is slight evidence for an association between arsenic exposure and fetal growth, based on twenty medium or high confidence studies covering diverse geographic regions (e.g., United States, China, Bangladesh). Studies using a variety of exposure assessment methods and covering a range of overlapping exposure levels had unexplained inconsistency with positive [e.g., (Signes-Pastor et al., 2019a; Shih et al., 2020)] and inverse [e.g., (Liu et al., 2018; Liao et al., 2018; Goodrich et al., 2019)] associations with a variety of fetal growth parameters. There is coherence with the evidence for birth weight and some of the evidence for postnatal growth and prematurity.

There is slight evidence for an association between arsenic and prematurity. Eighteen medium or high confidence cohort and cross-sectional studies evaluated the association between arsenic exposure (evaluated using a range of exposure assessment approaches) and prematurity. Most studies reported no association, but seven studies representing both higher and lower exposure scenarios reported positive associations (Röllin et al., 2016; Rahman et al., 2017a; Nyanza et al., 2020; Laine et al., 2015; Almberg et al., 2017; Ahmad et al., 2001; Aelion et al., 2012). There in unexplained inconsistency in these studies covering overlapping arsenic exposure levels. There is some evidence of a dose-response gradient across studies, with some stronger effects documented in areas with higher arsenic exposures [e.g., (Rahman et al., 2017a)] compared with lower arsenic exposures [e.g., (Almberg et al., 2017)].

There is also slight evidence for the association between prenatal arsenic exposure and postnatal growth based on significant associations in two (Wai et al., 2020; Muse et al., 2020) of six medium or high confidence studies. There is unexplained inconsistency in this small evidence base. There is coherence with the evidence for birth weight and some of the evidence for fetal growth.

There is some evidence regarding potential modifying factors (sex, nutritional status, smoking, and maternal prepregnancy weight) that may impact the association between arsenic and fetal, newborn, and infant health outcomes.

Overall, the currently available epidemiologic evidence indicates that iAs likely causes adverse fetal, newborn, and infant health outcomes in humans given sufficient exposure conditions. This conclusion is based on epidemiological studies at a variety of exposure levels (including <100 μg/L (and also including <20 μg/L) showing associations between iAs exposure and adverse fetal, newborn, and infant health outcomes. Therefore, fetal, newborn, and infant health outcomes will be considered for dose-response analysis (see Section 4.4).

Table 3-7 Evidence profile table for epidemiological evidence on iAs and fetal, newborn, and infant health outcomes

Evidence stream summary and interpretation
Evidence from studies of exposed humans
Studies | Summary of key findings | Factors that increase certainty | Factors that decrease certainty | Evidence synthesis judgment(s)
Fetal & infant mortality; 13 medium or high confidence studies | The strongest evidence of positive associations comes from largely consistent cohort and cross-sectional studies conducted in Bangladesh and India, where iAs levels in drinking water wells commonly exceed 200 μg/L. Other studies, including in other regions of the world, provide evidence at lower levels of exposure (e.g., <100 μg/L) | - Studies are medium or high confidence; - Consistency – across geographic regions, study types, and outcome metrics; - Dose-response gradient – for some but not all studies | - Imprecision – some studies with large confidence intervals including the null | ⊕⊕⊙; Moderate
Birth weight; 36 medium or high confidence studies | Studies across diverse geographic regions representing a range of exposure levels and utilizing a variety of exposure assessment methods provide generally consistent results indicating statistically significant and nonsignificant inverse associations between iAs and birth weight. | - Studies are medium or high confidence.; - Consistency – across geographic regions and study types; - Coherence – with some evidence from fetal growth, prematurity, and postnatal growth evidence | - Imprecision – some studies with large confidence intervals including the null | ⊕⊕⊙; Moderate
Fetal growth; 24 medium or high confidence studies | Studies from diverse geographic regions covering overlapping exposure levels provide conflicting results for a variety of fetal growth parameters. Inverse associations are observed in regions with both high (e.g., Bangladesh, China) and low (e.g., United States) arsenic exposure. | - Studies are medium or high confidence.; - Coherence – with evidence for birth weight and some of the evidence for postnatal growth and prematurity | - Unexplained inconsistency – between studies with overlapping exposure levels; - Imprecision – some studies with large confidence intervals including the null | ⊕⊙⊙; Slight
Prematurity; 18 medium or high confidence studies | Most studies reported no association, but seven studies representing both higher and lower exposure scenarios reported significant positive associations. | - Studies are medium or high confidence.; - Dose-response gradient – some evidence of stronger effects in areas with higher arsenic exposures compared with lower arsenic exposures | - Unexplained inconsistency – between studies with overlapping exposure levels; - Imprecision – some studies with large confidence intervals including the null | ⊕⊙⊙; Slight
Postnatal growth; 6 medium or high confidence studies | Two studies (one in Bangladesh, one in USA) document changes in postnatal growth in relation to prenatal exposure but four studies at overlapping exposure levels document no significant associations. | - Studies are medium or high confidence.; - Coherence – with birth weight and some fetal growth evidence | - Unexplained inconsistency – between studies with overlapping exposure levels; - Imprecision – some studies with large confidence intervals including the null | ⊕⊙⊙; Slight

### 3.2.4 Neurodevelopmental Effects

#### Database Overview

In 2013, the NRC concluded that low-to-moderate levels of inorganic arsenic (iAs) are associated with neurological deficits based on evidence from both human and animal studies (NRC, 2013). As a result, evaluation of neurodevelopmental toxicity was categorized as a priority outcome by the NRC and recommended for consideration for dose-response analysis in the IRIS Toxicological Review. As described in the protocol (link provided in Appendix A) and supported by the (NASEM, 2019), the assessment focuses on the epidemiological evidence to highlight those studies in humans that best support dose-response analysis. On the basis of the analysis of epidemiological evidence, the strength of evidence was considered “moderate” which corresponds to an evidence judgment that the currently available evidence indicates that iAs likely causes neurodevelopmental effects in humans.

There are 85 studies that report on the association between arsenic exposures and neurodevelopmental effects. The publications underwent study evaluation, and 63 of the studies were considered medium or high confidence. Of the remaining studies, 19 were considered low confidence or uninformative due to limitations as noted in HAWC (see HAWC (https://hawc.epa.gov/assessment/100500243/)), and three identified in the 2022 search update were not considered further due to lack of hazard and/or dose-response utility (see Section 1.6.1). Citations of studies broken down by confidence level, type of neurodevelopmental outcome, and studies from the post-2019 literature updates that were not further considered in the assessment can be accessed via the interactive HAWC literature tag-tree visual presented in Figure 3-39. Because of the abundance of the evidence base, the subsequent synthesis is focused on the medium and high confidence studies as described in the protocol and supported by the NASEM (NASEM, 2019). Mechanistic studies and studies that evaluated various risk modifiers (e.g., life stage, sex, and environmental co-exposures) also provide some evidence that early-life exposure to arsenic and co-exposures to lead might increase susceptibility to arsenic-associated neurodevelopmental effects.

Figure 3-39 Literature tree for epidemiological studies assessing neurodevelopmental effects (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Neurodevelopmental-studies/))

#### Evidence from Epidemiological Studies

This section summarizes the epidemiological studies that evaluated an association between iAs exposure and neurodevelopmental outcomes. Key considerations in evaluating these studies are reviewed in Section 1.6.2. Because of the extended timeline of brain development, critical windows of exposure to arsenic extend from pregnancy through adolescence (Rice and Barone, 2000). Evidence indicates that arsenic accumulates in the brain (Sánchez-Peña et al., 2010). Additional considerations regarding potential susceptibility based on arsenic metabolism and distribution are reviewed in Section 1.5.1. The information below is organized by type of neurodevelopmental effect: (1) developmental neurocognitive effects; (2) social, behavioral, and emotional effects; (3) motor effects, and (4) general/crosscutting developmental delays.

##### Developmental neurocognitive effects

Forty-five epidemiological studies assessed an association between arsenic and developmental neurocognitive function in children and classified as medium or high confidence (see Figure 3-40). The studies primarily evaluated cognition using tests to measure learning, short- and long-term memory, verbal comprehension, perceptual reasoning, processing speed, executive function, and visuospatial function.

Figure 3-40 Study evaluation ratings for references evaluating developmental neurocognitive effects (see [underlined: interactive version in HAWC])

###### Cohort and case-control studies

Seventeen medium or high confidence cohort and case-control studies examined the association between arsenic exposure and developmental neurocognitive effects in young children and adolescents in Taiwan (Jiang et al., 2022), China (Wang et al., 2022b; Chen et al., 2023), Bangladesh (Wasserman et al., 2016; Vahter et al., 2020; Tofail et al., 2009; Rodrigues et al., 2016; Hamadani et al., 2010; Hamadani et al., 2011), Nepal (Parajuli et al., 2014; Parajuli et al., 2015b; Parajuli et al., 2015a), the United States (Signes-Pastor et al., 2022; Nozadi et al., 2021), Spain (Soler-Blasco et al., 2022), Tanzania (Nyanza et al., 2021), and Canada (Patti et al., 2022) (see Figure 3-41).

Some cohort studies on the linkage between arsenic and developmental neurocognitive effects suggest that results may differ based on timing of exposure or outcome assessment. For example, three prospective cohort studies evaluated the association between arsenic and developmental neurocognition using a cohort of maternal-infant pairs in Nepal (Parajuli et al., 2014; Parajuli et al., 2015b; Parajuli et al., 2015a). These studies estimated in utero exposure using arsenic levels in cord blood (mean 1.33 μg/L) and assessed mental development index (MDI) from the Bayley Scale of Infant Development at 6 months (Parajuli et al., 2014), 24 months (Parajuli et al., 2015a), and 36 months of age (Parajuli et al., 2015b). No statistically significant association was found between arsenic exposure in cord blood at delivery and mental development at any time point (6, 24, or 36 months of age; n = 94, 74, and 70, respectively), though suggestive positive and inverse associations were observed (beta (95% CI); 6 months: 1.01 (−4.53, 6.55); 24 months: −10.15 (−25.54, 5.23); 36 months: 2.55 (−9.07, 14.17)) (Parajuli et al., 2014; Parajuli et al., 2015a; Parajuli et al., 2015b). Maternal arsenic methylation, which results in lower exposure of toxic metabolites to the fetus, increases with advancing gestation (Section 1.5.1), which may partially explain these null results for late pregnancy exposure.

In Bangladesh, three studies evaluated high-level arsenic exposure and developmental neurocognition using a cohort of pregnant women enrolled in the Maternal and Infant Nutritional Intervention at Matlab (MINIMat) study (Hamadani et al., 2010; Hamadani et al., 2011; Tofail et al., 2009) (see Figure 3-41). Tofail et al. (2009) assessed problem solving in infants (mean age 7.4 months); the authors estimated in utero arsenic exposure using maternal urinary arsenic levels at gestational week (GW) 8 and 30 (median: 81 and 84 μg/L, respectively). These exposure windows capture both early and late pregnancy. The authors found no associations with problem solving. A follow-up study by Hamadani et al. (2010) assessed mental development in infants 18 months of age; the authors also evaluated language comprehension and expression. Consistent with Tofail et al. (2009), Hamadani et al. (2010) found no association between either maternal urinary (mean: 96.3 μg/L) or infant urinary arsenic levels (mean: 34.6 μg/L) and impaired neurodevelopment. For both of these studies, the authors posited that the impacts of exposure may become more apparent at later ages.

Hamadani et al. (2011) followed up with children from the same cohort at 5 years of age and assessed IQ with maternal urinary arsenic and urinary arsenic levels in children. A statistically significant inverse association between verbal IQ score and arsenic was found based on both maternal urinary arsenic at GW 8 (beta (95% CI): −0.9 (−1.7, −0.13) and child urinary arsenic at 1.5 years of age (beta (95% CI): −0.9 (−1.7, −0.10). Early gestation (i.e., GW 8) may be a particular window of vulnerability, given limited maternal arsenic methylation capacity (Section 1.5.1). When stratified by sex, the authors observed a statistically significant association between higher maternal urinary arsenic levels (GW 8 and GW 30) and child urinary arsenic levels (5 years of age) and decreased verbal IQ score in girls but not in boys. Similarly, in the stratified analysis, a significant association was found between decreased full-scale IQ score and maternal and child urinary arsenic levels at GW 30 and 5 years of age, respectively, in girls but not in boys (Hamadani et al., 2011).

Additional cohort studies utilizing a variety of exposure markers, including fingernail, urine, hair, and cord blood from diverse countries, including China, Taiwan, United States, Canada, Spain, and Bangladesh (Wang et al., 2022b; Vahter et al., 2020; Soler-Blasco et al., 2022; Signes-Pastor et al., 2022; Patti et al., 2022; Nozadi et al., 2021; Jiang et al., 2022; Chen et al., 2023) also suggest the potential importance of exposure timing. Maternal urinary arsenic in early pregnancy (median: 82 μg/L), but not late pregnancy, showed inverse associations with full developmental scores (quintiles 2–4: beta (95% CI): −4.52 (−8.61, −0.43); −5.91 (−10.0, −1.77); −5.98 (−10.2, −1.77), respectively, compared with quintile 1) and with verbal comprehension (quintiles 2–4: beta (95% CI): −1.90 (−3.24, −0.56); −1.50 (−2.86, −0.15); −1.89 (−3.27, −0.50), respectively, compared with quintile 1) in a cohort in Bangladesh (Vahter et al., 2020). These differing results based on different stages of pregnancy (early vs. late) may reflect changes in maternal arsenic metabolism over increasing gestation (see Section 1.5.1). In another cohort study looking at early pregnancy exposures, authors observed that urinary monomethylarsonic acid (MMA) concentrations measured in the first trimester of pregnancy (geometric mean: 0.34 μg/g) were inversely associated with the scores for the general, verbal, quantitative, memory, and working memory scales of children aged 4–5 years in Spain (beta (95% CI); general: −1.37 (−2.33, −0.41); verbal: −1.18 (−2.13, −0.23); quantitative: −1.23 (−2.20, −0.27); memory: −1.19 (−2.17, −0.20); working memory: −0.96 (−1.90, −0.02)) (Soler-Blasco et al., 2022). Similarly, in Canada, first trimester urinary DMA concentrations (median: 2.23 μg/L) were associated with decreased odds of optimal neurodevelopment at 3 years of age (based on both cognitive and behavioral components), though the confidence interval included the null (OR (95% CI): 0.44 (0.19, 1.02) (Patti et al., 2022). Effects were more mixed when evaluating periods of exposure that included later pregnancy or delivery. For example, maternal urinary arsenic measurements at 26 weeks pregnancy (median (IQR): 3.63 (2.40–5.86) μg/L) was associated with suggestive decreases (with confidence intervals including the null) in mental development index (MDI) as well as full-scale IQ (FSIQ) among a U.S. cohort (n = 260) of children at ages 2, 3,5, and 8 years old (beta (95% CI); MDI at 2 years: −1.1 (−3.5, 1.2); MDI at 3 years: −1.8 (−4.1, 0.5); FSIQ at 5 years: −2.5 (−5.1, 0.0); FSIQ at 8 years: −1.7 (−4.5, 1.1)) (Signes-Pastor et al., 2022).

In some cases, however, periods of exposure that included later pregnancy still demonstrated adverse effects with developmental neurocognitive effects. For example, in the Navajo Birth Cohort Study (n = 327), arsenic measured in maternal urine at the time of delivery (geometric mean: 6.13 μg/L) was inversely associated with problem-solving scores in infants at ages 10 to 13 months (beta (SD): −1.25 (0.48)) (Nozadi et al., 2021). Similarly, in a cohort from China (n = 148), authors examined intelligence in school-aged children (mean = 7.5 years). Using cord blood arsenic concentrations at delivery (median (IQR): 1.64 (0.76–2.93) μg/L), the authors observed suggestive inverse associations with children’s verbal intelligence quotient, with stronger and statistically significant impacts in girls at lower exposures (Q2 vs. ref: −13.63 (−24.16, −3.09); Q3 vs. ref: −5.25 (−14.81, 4.32); Q4 vs. ref: −3.54 (−14.02, 6.94)) (Wang et al., 2022b). Another cohort study based in China observed that urinary iAs during pregnancy (GM averaged across three trimesters: 3.26 μg/L) was associated with decreased MDI scores in children at age 2 years (beta (95% CI): −2.45 (−4.86, −0.05)) (Chen et al., 2023). However, in a cohort based in Taiwan, there was no association between meconium arsenic concentrations and cognitive and language scores at age 3 (Jiang et al., 2022).

Figure 3-41 Thumbnail schematic of cohort and case-control studies addressing the association between inorganic arsenic exposure and developmental neurocognitive effects (a) difference measures, urine biomarkers, continuous exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Neurodevelopment-Cohort-Studies-Coefficient-urine/); (b) difference measures, non-urine biomarkers, continuous exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Neurodevelopment-Cohort-Studies-Coefficient-b-9234/); (c) difference measures, biomarkers, categorical exposure (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Neuro-cognitive-cohort-categorical/) (see interactive data graphic)

(a) Difference measures, urine biomarkers, continuous exposures

(b) Difference measures, nonurine biomarkers, continuous exposures

(c) Difference measures, biomarkers, categorical exposures

###### Cross-sectional & ecological studies

Additional evidence for an association between arsenic exposure and developmental neurocognitive deficits comes from 27 cross-sectional studies conducted in the United States (Wright et al., 2006; Wasserman et al., 2014; Stein et al., 2022); Mexico (Rosado et al., 2007; Rocha-Amador et al., 2007; Calderón et al., 2001); Bangladesh (Wasserman et al., 2004; Wasserman et al., 2007; Wasserman et al., 2011; Wasserman et al., 2018; Saxena et al., 2022; Nahar et al., 2014b; Nahar et al., 2014a); China (Zhou et al., 2020; Wang et al., 2006; Pan et al., 2018); Taiwan (Kao et al., 2023a); India (von Ehrenstein et al., 2007; Vaidya et al., 2023); Cambodia (Vibol et al., 2015); Vietnam (Egwunye et al., 2022); Uruguay (Desai et al., 2018; Desai et al., 2020b; Desai et al., 2020a); Italy (Lucchini et al., 2019); and Spain (Rodríguez-Barranco et al., 2016; Signes-Pastor et al., 2019b) (see Figure 3-42). The majority of the cross-sectional studies evaluated populations that had experienced chronic or lifelong exposure to arsenic, reducing concern about temporality normally present for this study design. There was also one ecological study based in Australia (Dong et al., 2015) as well as one cross-sectional analysis from a cohort study (Vahter et al., 2020).

In several studies from the United States, the relationship between arsenic exposure and intellectual function was examined among school-aged children (see Figure 3-42). Wasserman et al. (2014) used arsenic levels in drinking water and toenails (mean 9.88 μg/L and 4.65 μg/g, respectively) to estimate arsenic exposure with intellectual quotient (IQ) and cognitive performance. Compared with children exposed to <5 μg/L arsenic in drinking water, those exposed to arsenic levels 5–10 μg/L had statistically significantly lower FSIQ scores and lower scores in perceptual reasoning, working memory, and verbal comprehension (beta (SE); FSIQ: −6.09 (1.98); perceptual reasoning: −4.97 (2.14); working memory: −4.88 (2.24); verbal comprehension: −6.22 (2.49). No association was observed between these measures of intellectual function and toenail arsenic concentrations (Wasserman et al., 2014). Wright et al. (2006) measured arsenic levels in hair (mean 17.8 ppb) of children (11–13 years old) in the U.S. and assessed IQ, complex nonverbal cognitive abilities, verbal learning and memory, and learning and memory. The authors reported a statistically significant inverse association between hair arsenic levels and verbal IQ and FSIQ (beta (SE); verbal IQ: −0.51 (0.16); FSIQ: −0.44 (0.17)) (see Figure 3-42). Stein et al. (2022) also observed inverse associations between hair arsenic (median: 0.018 μg/g) and both full-scale IQ and verbal IQ, though confidence intervals included the null (beta (95% CI); full-scale IQ: −0.73 (−2.32, 0.86); verbal IQ: −1.02 (−2.63, 0.59)).

Figure 3-42 Thumbnail schematic of cross-sectional studies addressing the association between iAs exposure and developmental neurocognitive effects (a) difference measures, blood biomarkers, continuous exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Neurodevelopment-Cross-sect-Studies-Coef-bloo/); (b) difference measures, non-blood biomarkers, continuous exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Neurodevelopment-Cross-sectional-Studies-bioma-IQ/); (c) difference measures (latency & omission tests), non-blood biomarkers, continuous exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/developmental-neurocog-cross-sectional-differ-47fe/); (d) ratio measures (for impaired scores), biomarkers, continuous exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Neuro-cognitive-Cross-sectional-Studies-ratio-a839/); (e) difference measures, drinking water, continuous exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Neurodevelopment-Cross-sectional-Studies-Coef-e978/); (f) difference measures, drinking water, categorical exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/developmental-neurocognitive-cross-sectional-0a81/) (see interactive data graphic)

(a) Difference measures, blood biomarkers, continuous exposures

(b) Difference measures, non-blood biomarkers, continuous exposures

(c) Difference measures (latency & omission tests), non-blood biomarkers, continuous exposures

(d) Ratio measures (for impaired scores), biomarkers, continuous exposures

(e) Difference measures, drinking water, continuous exposures

(f) Difference measures, drinking water, categorical exposures

In Mexico, students (6–8 years of age) living near a metallurgical smelter complex had cognitive effects measured, along with urinary arsenic (Rosado et al., 2007). The authors reported a significant inverse association between urinary arsenic levels (mean = 58.1 μg/L) and problem solving and vocabulary, memory, and attention scores. A statistically significant association was seen between urinary arsenic levels ≤50 μg/L and deficits in problem solving, vocabulary, and memory scores. Among children with urinary arsenic levels >50 μg/L, a statistically significant association was observed between urinary arsenic and deficits in problem solving, vocabulary, and attention scores. Also in Mexico, Rocha-Amador et al. (2007) studied children (6–10 years of age) in three rural areas where mean arsenic levels in drinking water ranged from 5.8 to 194 μg/L. The authors observed a statistically significant inverse association between urinary arsenic and full IQ scores (beta: −5.72) and nonsignificant associations with performance (beta: −4.19) and verbal IQ scores (beta: −5.50). All three outcomes were statistically significant in relation to drinking water (performance IQ: −4.30; verbal IQ: −6.40; full IQ: −6.15) (Rocha-Amador et al., 2007). Calderón et al. (2001) studied children (mean age = 7.5 years) in two Mexican communities (Martinez and Morales: mean urinary arsenic concentration 40.3 μg/g and 62.9 μg/g creatinine, respectively). While at the community level, the authors reported significantly lower full-scale (p = 0.023) and verbal IQ scores (p = 0.038) in Martinez (lower arsenic exposure) compared with Morales (higher arsenic exposure), they reported inverse correlations between urinary arsenic and several measures of intelligence among children in Morales (higher arsenic exposure) and between urinary arsenic and verbal IQ for both populations overall (Calderón et al., 2001).

Several cross-sectional studies identified in the literature review were conducted in India (von Ehrenstein et al., 2007; Vaidya et al., 2023) and Bangladesh (Nahar et al., 2014b; Nahar et al., 2014a; Wasserman et al., 2004; Wasserman et al., 2007; Wasserman et al., 2011; Saxena et al., 2022). For example, von Ehrenstein et al. (2007) used validated tests to assess neurodevelopmental effects in children 5–15 years of age in India. The authors reported a statistically significant inverse association between child urinary arsenic levels (mean = 78 μg/L) and performance on vocabulary and picture completion tests (>82.6 μg/L vs. ref; vocabulary: −0.28 (−0.55, −0.008); picture completion: −0.26 (−0.51, −0.01)). Also in India, urinary arsenic at ages 6–23 years was inversely associated with several measures of concurrent executive function (beta (95% CI); attention: −0.05 (−0.09, −0.01); working memory: −0.05 (−0.08, −0.01); set-shifting: −0.03 (−0.07, −0.004)) (Vaidya et al., 2023). In Bangladesh, Nahar et al. (2014a) assessed IQ in children grouped by urinary arsenic level (aged 4–5 years (mean = 126 μg/L); 9–10 years (mean = 181.9 μg/L)). Among the 4- to 5-year-old children, there was a statistically significant difference in IQ by exposure group (low = 137 μg/L; medium: 137 < 400 μg/L; and high: >400 μg/L). Among the 9- to 10-year-old children, there was a statistically significant difference between IQ for the low versus medium exposure groups. Nahar et al. (2014b) used the same tests as Nahar et al. (2014a) to identify differences in IQ by arsenic exposure (mean drinking water arsenic levels = 71.7 μg/L; mean urinary arsenic levels = 205.3 μg/L) in adolescents (14–15 years of age) in Bangladesh. They identified lower IQ in groups with elevated arsenic (drinking water > 10 μg/L; urinary arsenic > 137 μg/L). In another study based in Bangladesh (Vahter et al., 2020), compared with the first urinary arsenic quintile at 10 years (<30 μg/L), children in the third and fourth quintiles (30–45 and 46–73 μg/L, respectively) had lower full developmental scores (beta (95% CI); third quartile: −7.23 (−11.3, −3.18); fourth quartile: −6.37 (−10.5, −2.22)). Analyses using children’s hair arsenic concentrations showed similar results (Vahter et al., 2020). Additionally, Saxena et al. (2022) examined adolescents in Bangladesh and observed a statistically significant inverse association between blood arsenic and spatial working memory (beta (SE): −2.40 (1.10)).

There were several other studies based in Bangladesh from the same author group. Wasserman et al. (2004) found a statistically significant inverse association between high arsenic levels in drinking water (mean = 117.8 μg/L) and both full-scale and performance IQ scores in children aged 10 years (beta; full-scale: −1.64; performance: −1.45). In a later study looking at children 6 years of age, Wasserman et al. (2007) reported a statistically significant inverse association between similarly high arsenic levels in drinking water (mean = 120.1 μg/L) and full-scale IQ, performance IQ, and processing speed (beta (SE); full-scale: −1.06 (0.57); performance: −0.48 (0.24); processing speed: −0.54 (0.28)). Wasserman et al. (2011) found a statistically significant inverse association between blood arsenic levels (mean = 4.81 μg/L) and verbal comprehension in 8–11-year-olds (beta (SE): −1.49 (0.71)); the association with full-scale IQ was borderline significant (beta (SE): −3.80 (2.20)). In adolescents aged 14–16 years in Bangladesh, Wasserman et al. (2018) reported blood arsenic (mean: 4.84 μg/L) and creatinine-adjusted urinary arsenic (mean: 158 μg/g creatinine) levels were significantly negatively associated with various metrics of child intelligence, including verbal comprehension, processing speed, working memory, and perceptual reasoning (urinary arsenic only). For example, a doubling of blood arsenic was associated with a mean IQ score decrement of 3.3 points (95% CI: 1.1, 5.5) while a doubling of creatinine-adjusted urinary arsenic was associated with a mean decrement of 3.0 points (95% CI: 1.2, 4.5) (see Figure 3-42).

Other cross-sectional studies identified in the literature review included those conducted in China, Vietnam, Cambodia, Taiwan, Spain, and Uruguay. In 36-month-old children (n = 658) in Vietnam, authors reported that fingernail arsenic concentrations (median (IQR): 0.4 (0.3–0.5) μg/g) were significantly associated with reduced language scores (beta (95% CI): −0.19 (−0.32, −0.05)) (Egwunye et al., 2022). In north-central China, Wang et al. (2006) studied children aged 8–12 years and examined the association between IQ score and arsenic levels in drinking water in a rural community. The authors reported statistically significant differences between mean arsenic levels in drinking water and IQ score in both the high (190 μg/L) and medium (142 μg/L) arsenic groups compared with the control group (2 μg/L). The IQ scores were 10 and 4 points lower, respectively, in the high and medium arsenic exposure groups compared with students in the control group. However, Pan et al. (2018) studied children aged 9–11 years to examine the association between IQ score and arsenic concentrations in blood and urine in southern China and observed no significant associations. Similarly, Zhou et al. (2020) observed no associations between arsenic concentration from children’s urine samples at age 7–8 years (median (IQR): 26.05 (12.88–43.80) μg/L) and concurrent IQ. And among normal-birth-weight children at 2 years of age in Taiwan, fingernail arsenic (central tendency not reported) was not associated with cognitive scores (Kao et al., 2023a).

In Spain, Rodríguez-Barranco et al. (2016) assessed the association between urinary arsenic (geometric mean = 0.7 μg/L) and neurodevelopmental effects in children aged 6–9 years, finding statistically significant associations between higher concentrations of arsenic and impaired reaction time, including increased latency in the selective attention and simple reaction time tests (beta (95% CI); selective attention: 3.58 (0.37, 6.79); simple reaction time: 12.31 (3.51, 21.22)). Another study from Spain examining neuropsychological development observed suggestive inverse associations with the scores in the quantitative index and working memory function only in boys, using a spot urine sample (median: 4.85 μg/L) at ages 4–5 years (beta (95% CI); quantitative index: −2.69 (−5.36, 0.17); working memory: −2.56 (−5.36, 0.24)) (Signes-Pastor et al., 2019b).

In Uruguay, Desai et al. (2018) assessed the association between urinary arsenic levels (median: 11.6 μg/L) and cognitive performance in 5–8 year old children; no statistically significant associations between arsenic and cognitive abilities were seen. Similarly, Desai et al. (2020a) found no significant associations between urinary arsenic (median: 11.7 μg/L) and academic achievement measures. However, Desai et al. (2020b) found that urinary arsenic (median: 9.9 μg/L) was inversely associated with visual attention measures, including the number of stages completed in the visual attention task (beta (95% CI): −0.02 (−0.03, −0.002), pre-executive shift errors in the visual attention task (beta (95% CI): −0.08 (−0.14, −0.02)), and span length of the spatial-memory task (beta (95% CI): −0.01 (−0.02, −0.004)).

###### Summary

Medium and high confidence studies covering a range of exposure levels across diverse geographic regions and evaluating varying measures of developmental neurocognitive outcomes provide general consistency regarding the effect of arsenic on developmental neurocognition. A dose-response gradient was observed in some analyses [e.g., (Wasserman et al., 2004)]. There is coherence with the evidence of effects on social, behavioral, and emotional effects, motor effects, and developmental delays (described below). Some inconsistencies across the results reviewed in this section may be due in part to variations in the age of assessment of the exposure and outcome, though there are not sufficient data to confirm these explanations. There are also some unexplained inconsistencies. There is some imprecision in the observed results, as some studies have large confidence intervals that include the null.

##### Social, behavioral, and emotional effects

The systematic literature review identified 21 medium or high confidence epidemiological studies (see Figure 3-43) that evaluated the relationship between iAs and social, behavioral, and emotional effects in children. The studies primarily evaluated behavioral function and disorders, autism spectrum disorder, attention-deficit/hyperactivity disorder-related behaviors, anxiety and depression, and personal-social development (see Figure 3-44).

Four of these were case-control studies examining the association between arsenic and autism spectrum disorder (ASD), (Skogheim et al., 2021; Rahbar et al., 2021; Nabgha-e-Amen et al., 2020; Adams et al., 2013). In the Norwegian Mother, Father and Child Cohort, authors observed increased odds of autism spectrum disorder in relation to the second quartile of As exposure from a GW 17 maternal blood sample (2nd quartile of exposure = 1.01–1.59 μg/L; OR = 1.77 (05% CI: 1.26–2.49)), (Skogheim et al., 2021). Similarly, a study from Pakistan observed a large association between arsenic in hair and ASD risk in children (OR: 18.29 (95% CI: 1.98, 169.05); mean: 0.33 μg/g hair in cases vs. 0.21 μg/g in controls) as well as with urinary arsenic (OR: 1.04 (95% CI: 1.01, 1.06); mean: 36.67 μg/g creatinine in cases vs. 15.65 μg/g creatinine in controls) (Nabgha-e-Amen et al., 2020). However, another study in Pakistan observed no statistically significant difference in adjusted geometric mean arsenic blood concentration for controls (1.29 μg/L) compared with autism cases (1.47 μg/L) (Rahbar et al., 2021). In the U.S., Adams et al. (2013) evaluated the association with autism in children 5–16 years of age; they found no significant difference in median arsenic levels in whole blood or urine between controls and cases (mean blood: ASD cases: 3.30 μg/L; controls: 3.37 μg/L; mean urine: ASD cases: 30.8 μg/g; 17.9 μg/g).

Twelve cross-sectional studies across different countries examined other behavioral, social and emotional effects in children (Vaidya et al., 2023; Stein et al., 2022; Roy et al., 2011; Rodríguez-Carrillo et al., 2022; Rodríguez-Barranco et al., 2016; Renzetti et al., 2021; Nahar et al., 2014b; Ma et al., 2023; Huang et al., 2023; Egwunye et al., 2022; Dai et al., 2023). Many studies reported positive or suggestive positive associations (i.e., more reported problems with higher exposures). For example, in a cross-sectional study in Spain, authors observed the second tertile of urinary arsenic (6.47–16.18 μg/g) to be associated with internalizing problems in children, including anxiety and somatic problems (beta (95% CI): internalizing problems: 5.87 (0.52, 11.22); anxious-depressed: 4.0 (0.87, 7.13); somatic complaints: 5.58 (1.66, 9.50) (Rodríguez-Carrillo et al., 2022). In a cross-sectional study in Italy, urinary arsenic (median: 8.3 μg/L) was associated with increased neurobehavioral problems, including anxious-depressed, somatic complaints, attention problems, and rule-breaking behavior (beta (95% CI): anxious-depressed: 0.8 (0.1, 1.5); somatic complaints: 1.5 (0.1, 2.9); attention problems: 0.9 (0.2, 1.7); rule-breaking behavior: 0.9 (0.2, 1.7)) (Renzetti et al., 2021). In Mexico, Roy et al. (2011) reported modest associations in a cross-sectional study using urinary arsenic levels (median of 55.2 μg/L) in students (6–8 years of age). Compared with the lowest quartile (7.7–35.9 μg/L) of urinary arsenic, those in the 2nd quartile (36–55 μg/L) had higher scores on the oppositional behavior rating (beta (95% CI): 3.1 (0.01, 6.1)), but effect estimates in the higher quartiles overlapped with the null (Roy et al., 2011). In the United States, there were some associations between hair arsenic among 6- to 12-year-olds (median: 0.018 μg/g) and parent-reported ADHD-like behaviors (e.g., inattentive, hyperactive), though confidence intervals included the null (beta (95% CI); ADHD T-score: 1.14 (−0.4, 2.7); inattentive T-score: 1.02 (−0.4, 2.4); hyperactive T-score: 1.04 (−0.35, 2.43)) (Stein et al., 2022). Associations between urinary arsenic at 6–9 years (geometric mean: 0.70 μg/L) and ADHD-like behaviors were also observed in a cohort in Spain (beta (95% CI); impulsivity: 0.6 (0.1, 1.1); inattention: 0.5 (0.03, 1.0)) (Rodríguez-Barranco et al., 2016). However, some studies in Taiwan and China reported no significant associations between urinary arsenic at 3–6 years (mean in Taiwan: 102.1 μg/g creatinine; median in China: 33.86 μg/L −40.75 μg/g creatinine) and behavioral problems (Ma et al., 2023; Huang et al., 2023; Dai et al., 2023). Yet, in one of the studies based in China, urinary arsenic (median: 33.86 μg/L) was associated with anxious and depressed behavior scores among girls only (beta (95% CI): 0.71 (0.12, 2.31)) (Dai et al., 2023).

There were also seven prospective cohort analyses evaluating this association (Patti et al., 2022; Nyanza et al., 2021; Nozadi et al., 2021; Lozano et al., 2024; Liang et al., 2020; Karakis et al., 2021; Dai et al., 2023). Study results were overall mixed. In a prospective cohort in China (n = 2,315 mother-infant pairs), the status of children’s development and behavior at 6 months postpartum was assessed in relation to cord serum arsenic levels (Liang et al., 2020). Compared with the low arsenic reference group (<1.27 μg/L), medium (1.27–2.89 μg/L) and high (>2.89 μg/L) arsenic groups were associated with increased risks of a ‘significant development delay’ in the personal-social domain among infants (OR (95% CI); medium group: 1.33 (1.01, 1.75); high group: 1.47 (1.08, 2.00)) (Liang et al., 2020). In Canada, first trimester urinary DMA concentrations (median: 2.23 μg/L) were associated with decreased odds of optimal neurodevelopment at 3 years of age (based on both cognitive and behavioral components), though the confidence interval included the null (OR (95% CI): 0.44 (0.19, 1.02) (Patti et al., 2022). Among a cohort in Spain, MMA averaged across the first and third trimesters (GM: 0.34 μg/g) was associated with increased total emotional and behavioral problems among children at 9 years of age (IRR (95% CI): 1.06 (1.01, 1.12)); results were attenuated for models based on total arsenic (GM: 49.59 μg/g) and iAs (GM: 0.32 μg/g) (IRR (95% CI); total arsenic: 1.01 (0.97, 1.04); iAs: 1.03 (0.98, 1.08)) (Lozano et al., 2024). However, some studies observed no associations. For example, a cohort study from Israel found no association between arsenic from a maternal urine sample collected prior to delivery (geometric mean: 3.59 ppb) and child behavioral disorders (Karakis et al., 2021). Similarly, a study in China did not observe associations between maternal urinary arsenic during pregnancy (median: 22.22 μg/L) and child behavioral problems at 6 years of age (Dai et al., 2023). In Tanzania, there was no association between prenatal total arsenic (median: 8.3 μg/L) and social development at 6–12 months of age.

###### Summary

There is slight evidence for an association between arsenic exposure and social, behavioral, and emotional effects based on 21 medium or high confidence studies across diverse geographic regions and using different types of exposure biomarkers. Four case-control studies examined autism, with unexplained inconsistency of findings across these studies. Thirteen cross-sectional, case-control, and cohort studies evaluated impacts on a variety of other behavioral and emotional endpoints. Many of these studies indicated associations or suggestive associations with arsenic; some of the variations in the evidence base may be due to the range of endpoints evaluated in this outcome category, though this explanation cannot be confirmed, and there may also be other unexplained considerations. There is coherence with the evidence bases for developmental neurocognitive effects and some of the evidence for motor effects and developmental delays. There is some imprecision in the observed results, as some studies have large confidence intervals that include the null.

Figure 3-43 Study evaluation ratings for references evaluating social, behavioral, and emotional effects (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Developmental-delay-intellectual-disability-o-0160/))

Figure 3-44 Thumbnail schematic of studies addressing the association between inorganic arsenic exposure and social, behavioral, and emotional effects (a) difference measures, biomarkers, continuous exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Neuro-social-cross-sectional-studies-coeffici-7acd/); (b) difference measures, biomarkers, categorical exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/social-behav-emotional-biomarkers-difference-446f/); (c) ratio measures, biomarkers, continuous exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/social-behav-emotional-biomarkers-ratio-measu-e113/) (see interactive data graphic)

(a) Difference measures, biomarkers, continuous exposures

(b) Difference measures, biomarkers, categorical exposures

(c) Ratio measures, biomarkers, continuous exposures

##### Motor effects

Fifteen medium and high confidence studies, using four different exposure measures, examined motor functions and skills across diverse areas (such as Bangladesh, Nepal, Vietnam, United States, Spain, China, and Taiwan) (Tofail et al., 2009; Soler-Blasco et al., 2022; Signes-Pastor et al., 2019b; Parvez et al., 2011; Parajuli et al., 2014; Parajuli et al., 2015b; Parajuli et al., 2015a; Nyanza et al., 2021; Nozadi et al., 2021; Kao et al., 2023a; Jiang et al., 2022; Hamadani et al., 2010; Egwunye et al., 2022; Chen et al., 2023; Butler et al., 2023) (see Figure 3-45 and Figure 3-46).

Five of these studies were cross-sectional (Signes-Pastor et al., 2019b; Parvez et al., 2011; Kao et al., 2023a; Jiang et al., 2022; Egwunye et al., 2022). Most of these studies documented adverse effects on motor function. For example, one study investigated the association between arsenic and motor coordination in children aged 8–11 years in Bangladesh through various endpoints including body coordination, manual coordination, fine manual control, and strength and agility (Parvez et al., 2011). The authors observed inverse associations between total motor composite and body coordination scores and arsenic levels in drinking water (mean: 43.3 μg/L; beta (95% CI): body coordination (BC): −0.43 (−0.77, −0.06); total motor composite (TMC): −1.18 (−2.13, −0.10)), blood (mean: 4.8 μg/L; beta (95% CI); BC: −1.61 (−2.70, −0.51); TMC: −3.63 (−6.72, −0.54)), toenails (mean: 5.9 μg/g; beta (95% CI); BC: −1.86 (−2.83, −0.89); TMC: −3.77 (−6.52, −1.03)), and urine (mean: 246.5 μg/g creatinine; beta (95% CI); BC: −1.60 (−2.61, −0.60); TMC: −3.42 (−6.27, −0.57)) (Parvez et al., 2011). In Spain, authors observed inverse associations between several motor function scores and arsenic in urine among 4–5 year-olds (mean urinary arsenic levels: 4.85 μg/L; beta (95% CI): global score: −2.29 (−3.95, −0.63); gross score: −1.92 (−3.52, −0.31); fine score: −1.54 (−3.06, −0.03)) (Signes-Pastor et al., 2019b). Two studies of 2–3-year-olds from Taiwan observed that hair arsenic (median: 0.19 μg/g) or fingernail arsenic (central tendency not reported) were inversely associated with gross motor development [beta (95% CI): −0.032 (−0.061, −0.004) (Jiang et al., 2022)]; [beta (95% CI): −1.31 (−2.43, −0.19) (Kao et al., 2023a)]. However, in Vietnam, no significant association was observed between fingernail arsenic (median (IQR) = 0.4 (0.3–0.5) μg/g) and motor skills (Egwunye et al., 2022).

There were also 10 cohort studies that evaluated the impact of arsenic on motor function (Tofail et al., 2009; Soler-Blasco et al., 2022; Parajuli et al., 2014; Parajuli et al., 2015b; Parajuli et al., 2015a; Nyanza et al., 2021; Nozadi et al., 2021; Hamadani et al., 2010; Chen et al., 2023; Butler et al., 2023). Results were overall mixed, though some of the inconsistencies may be due to differences in timing of exposure or outcome ascertainment.

Three studies evaluated psychomotor development among a cohort in Nepal (Parajuli et al., 2014; Parajuli et al., 2015b; Parajuli et al., 2015a). These studies estimated in utero exposure using arsenic levels in cord blood (mean 1.33 μg/L) and assessed psychomotor development at 6 months (Parajuli et al., 2014), 24 months (Parajuli et al., 2015a), and 36 months of age (Parajuli et al., 2015b). While no statistically significant association was found between arsenic exposure in cord blood at delivery and psychomotor development at any time point, the earlier study documented suggestive inverse associations (beta (95% CI): −2.02 (−13.02, 8.98) (Parajuli et al., 2014), while the two later studies documented suggestive positive associations (beta (95% CI); 24 months: 5.51 (−13.60, 24.62); 36 months: 6.25 (−5.08, 17.58)) (Parajuli et al., 2015b; Parajuli et al., 2015a). Maternal arsenic methylation, which results in lower exposure of toxic metabolites to the fetus, increases with advancing gestation (Section 1.5.1), which may partially explain these inconclusive results for late pregnancy exposure.

In Bangladesh, two studies evaluated high-level arsenic exposure and motor impacts using a cohort of pregnant women enrolled in the Maternal and Infant Nutritional Intervention at Matlab (MINIMat) study (Tofail et al., 2009; Hamadani et al., 2010). Tofail et al. (2009) assessed psychomotor development in infants (mean age 7.4 months) in relation to in utero arsenic exposure using maternal urinary arsenic levels at gestational week (GW) 8 and 30 (median: 81 and 84 μg/L, respectively). These exposure windows capture both early and late pregnancy. The authors found suggestive positive associations with psychomotor development, though confidence intervals included the null (beta (95% CI): 0.9 (−0.9, 2.7)) (Tofail et al., 2009). A follow-up study by Hamadani et al. (2010) assessed psychomotor development in infants 18 months of age and documented slight inverse and slight positive associations of psychomotor development with infant urinary arsenic levels (mean: 34.6 μg/L) and maternal urinary arsenic levels (mean: 96.3 μg/L), respectively, though confidence intervals included the null (beta (95% CI); child urine: −0.07 (−1.5, 1.3); maternal urine: 0.3 (−1.3, 1.9)) (Hamadani et al., 2010). For both of these studies, the authors posited that the impacts of exposure may become more apparent at later ages.

In a cohort based in China, there were no associations between iAs during pregnancy (average GM across three trimesters: 3.26 μg/L) and fine and gross motor development (Chen et al., 2023). And in a cohort based in Tanzania, second trimester total urinary arsenic (median: 8.3 μg/L) was not associated with abnormal fine or gross motor development (Nyanza et al., 2021). However, among a cohort based in the United States, total urinary arsenic at 24–28 weeks gestation (second trimester) (median: 4.0 μg/L), was associated with decrements in motor development (linear model beta (95% CI); short form: −0.77 (−1.42, −0.13); fine motor integration: −0.23 (−0.62, 0.15); change-point model beta (95% CI); short form: −3.25 (−6.09, −0.40); fine motor integration: −4.29 (−7.95, −0.63)) (Butler et al., 2023).

###### Summary

From 15 medium and high confidence studies from diverse regions, many studies provide evidence of adverse or suggestive adverse motor effects. Some of the observed inconsistencies may be due to differences in the timing of exposure or outcome assessment, though this explanation cannot be confirmed. There may also be other unexplained factors. There is coherence with the evidence for developmental neurocognitive effects and some of the evidence for social, behavioral, and emotional effects and developmental delays. There is some imprecision in the observed results, as some studies have large confidence intervals that include the null.

Figure 3-45 Study evaluation ratings for references evaluating motor effects (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Motor-effects/))

Figure 3-46 Thumbnail schematic of studies addressing the association between inorganic arsenic exposure and motor effects: difference measures, biomarkers, continuous exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Neuro-motor-coefficient/) (see interactive data graphic)

##### Developmental delays

There were three medium confidence studies based in Taiwan that evaluated general developmental delays, composed of components across cognitive, social/behavioral/emotional, and motor domains, in relation to arsenic exposure (see Figure 3-47 and Figure 3-48). In a cross-sectional study of children in Taiwan, paternal and maternal toenail arsenic levels (median: 0.11–0.15 μg/g) but not child toenail arsenic (median: 0.19–0.22 μg/g) were associated with suspected developmental delays (beta (95% CI); paternal toenail: 13.52 (2.31, 78.94); maternal toenail: 5.09 (1.40, 18.41)) (Kao et al., 2023b). There were also two case-control studies from Taiwan evaluating this question. Hsieh et al. (2014) compared mean total urinary arsenic levels in children aged 4–6 years with (19.7 μg/L) and without (10.2 μg/L) developmental delays. Children in the highest tertile of arsenic exposure (total arsenic >24.7 μg/g creatinine) had an increased odds of developmental delay (OR (95% CI): 11.83 (1.52, 91.82)) (Hsieh et al., 2014). Similar results were obtained in a more recent study of children with and without developmental delay (third tertile (>18.46 μg/L) OR (95% CI): 2.67 (1.05, 6.77)) (Hsueh et al., 2022). Both of the case-control studies suggest a dose-response gradient (Hsueh et al., 2022; Hsieh et al., 2014).

Figure 3-47 Study evaluation ratings for references evaluating developmental delays (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Developmental-Delays-heatmap/))

Figure 3-48 Thumbnail schematic of studies addressing the association between inorganic arsenic exposure and developmental delays: difference measures, biomarkers, continuous exposures (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Neuro-motor-coefficient/) (see interactive data graphic)

#### Mechanistic Observations and Biological Plausibility

Researchers have proposed several potential mechanisms for a possible association between iAs and neurodevelopmental effects. Herrera et al. (2013) showed that oral administration of arsenic to mice at 50,000 μg/L was consistent with increased oxidative stress in the brain, resulting in reduced levels of glutathione and increased lipid peroxidation, which could lead to neurodevelopmental effects. Other studies have explored arsenic interaction with hormone binding domains such as the glucocorticoid receptor [GR]. Several studies suggest that alterations in GR transcription are linked to subsequent changes in hypothalamic-pituitary-adrenal [HPA] axis activity. The HPA axis is a major part of the neuroendocrine system; prenatal and early life stressors on this system have been shown to be associated with findings of developmental neurotoxicity (e.g., impaired stress response, depressive-like behaviors) following developmental iAs exposure in mice (Goggin et al., 2012; Martinez-Finley et al., 2011; Martinez-Finley et al., 2009; Martinez et al., 2008). The results observed in rodents suggesting that endocrine effects may result in developmental neurotoxicity are concordant with findings in the epidemiologic literature that show a correlation between early life exposure to iAs and impaired cognitive function (Wasserman et al., 2007).

Other studies in rats suggest that exposure to iAs could result in changes in the brain, such as the increased expression of neural cell adhesion molecules (Luo et al., 2013) or damage to nerve fiber tracts, including discontinued axons (Ríos et al., 2009). These are likely to be secondary events. However, it is possible that hormonal interactions—particularly with estrogen and thyroid hormones, which are essential for brain development—also could be responsible for the iAs-related changes in the developing brain (Hamadani et al., 2011). Overall, the specific underlying mechanism(s) by which iAs may be producing the observed adverse neurodevelopmental effects is yet to be fully elucidated.

As discussed above inorganic arsenic exposure has been associated with developmental neurotoxicity, specifically decreased cognitive and IQ in young children. Evidence from neurodevelopmental studies show that mice perinatally exposed to low levels of inorganic arsenic (50 ppb) exhibited dysregulation of the hypothalamic-pituitary-axis (HPA) (Martinez et al., 2008; Goggin et al., 2012). The HPA axis is a major part of the neuroendocrine system; prenatal and early life stressors on this system have been shown to be associated with findings of developmental neurotoxicity (e.g., impaired stress response, depressive-like behaviors) following developmental iAs exposure in mice 50 ppb (Martinez et al., 2008; Goggin et al., 2012). One component of the HPA axis is the corticosterone receptor (CR). These receptors are located in the hippocampus, amygdala, and lateral septum of the brain. The CR binds to corticosteroid hormones like cortisol and stimulates gene expression within brain cells impacting stress response, learning and memory. Martinez et al. (2008) showed that mice exposed to 50 ppb iAs prenatally displayed altered hippocampal CR, elevated serum corticosterone levels, and dysregulation of serotonin levels. Follow-up studies by this group showed that prenatally iAs exposed mice had fewer number of CR in the hippocampus versus control and displayed deficiencies in learning and memory (Martinez-Finley et al., 2009; Martinez-Finley et al., 2011). The evidence base demonstrates that moderate exposures to perinatal iAs can have adverse effects on learning, memory, and behavior (Martinez-Finley et al., 2009; Martinez-Finley et al., 2011; Martinez et al., 2008; Goggin et al., 2012) and provides biological plausibility to support the findings in the epidemiologic literature that show a correlation between early life exposure to iAs and deficiencies in cognitive development.

#### Risk Modifiers

A review of the epidemiological studies discussed in this section, along with studies identified from a targeted literature search (see Section 3.10 of iAs Protocol) on modifying factors identified in Table 3-8, suggest that the following factors increase the risk of arsenic-associated neurodevelopmental effects:

- Environmental co-exposures: Evidence is suggestive that co-exposures to lead result in an increased risk for neurodevelopmental effects in children, which might be expected as lead also is known to cause neurodevelopmental effects in children. Marlowe et al. (1985) and McDermott et al. (2011) indicate an interaction between arsenic and lead on neurodevelopmental effects, but neither indicates if the results are additive or greater than additive.
- Sex: Evidence is suggestive that sex may modify risk of neurodevelopmental effects. Some studies indicate that boys may be more susceptible to neurodevelopmental effects (Signes-Pastor et al., 2019b; Rosado et al., 2007), while others indicate that girls may be more susceptible (Wang et al., 2022b; Hamadani et al., 2011; Dai et al., 2023). In particular, girls appear to be more susceptible to impacts on measures of verbal IQ (Wang et al., 2022b; Hamadani et al., 2011).

Table 3-8 Risk modifiers for neurodevelopmental effects (selected study examples)

Risk modifiers | References | Finding | Population, exposure level
Environmental co-exposures | Marlowe et al. (1985) | Combination of arsenic and lead resulted in increased measures of acting out, disturbed peer relations, and immaturity in school-aged children | United States: 2.94 ppm (mean arsenic, hair); 6.65 ppm (mean lead, hair)
| Wasserman et al. (2011) | Combination of arsenic and manganese not related to decreased scores on intellectual function in school-aged children | Bangladesh: 117.8 μg/L (mean, water)
| Mcdermott et al. (2011) | Combination of arsenic and lead resulted in increased probability of intellectual disabilities in normal weight for gestational-aged infants | United States: 2.6 mg/kg (mean arsenic, soil); 35.4 mg/kg (mean lead, soil)
Sex | Rosado et al. (2007) | In tests related to problem solving and vocabulary, significant inverse associations were observed in boys but not girls | Mexico: 58.1 μg/L (mean, urine)
Sex | Hamadani et al. (2011); | Decrease in full-scale and verbal IQ in girls; low and non-statistically significant associations in boys | Bangladesh: 51 μg/L (median, urine)
| Signes-Pastor et al. (2019b) | Suggestive inverse associations with scores in the quantitative index and working memory function among boys only.; Inverse associations for overall motor score among boys, with attenuated suggestive inverse associations among girls | Spain: 4.85 μg/L (median, urine)
| Wang et al. (2022b) | Stronger and statistically significant impacts on verbal intelligence quotient among girls, especially at lower exposure levels | China: 1.64 μg/L (median, cord blood)
| Dai et al. (2023) | Urinary arsenic was associated with anxious and depressed behavior scores among girls only | China: 33.86 μg/L (median, urine)

#### Evidence Judgment

Across the body of evidence for neurodevelopmental effects, the currently available evidence indicates that iAs exposure likely causes neurodevelopmental effects in humans ((see (https://hawcprd.epa.gov/summary/assessment/100500243/tables/Neurodevelopmental/) Table 3-9) given sufficient exposure conditions.^23^ This conclusion is based on studies of humans that assessed exposure levels much lower than 100 μg/L (e.g., including <20 μg/L) primarily showing developmental neurocognitive effects and, to a lesser extent, social, behavioral, and emotional effects￼. (Supplemental figures of results from studies documenting adverse effects from exposure to inorganic arsenic in drinking water at concentrations less than or equal to 100 μg/L, as described in 1.6.3, are available in Appendix B.5.) Human studies assessing susceptible populations and modifying factors provide evidence that early-life exposure to arsenic and co-exposures to lead might increase susceptibility to arsenic-associated neurodevelopmental effects.

There is moderate evidence supporting an association between arsenic and developmental neurocognitive effects that comes from 45 medium or high confidence epidemiological studies. There is general consistency for inverse associations between arsenic exposure and childhood cognitive measures across diverse geographic locations covering a range of exposure levels and using various outcome and exposure metrics. Some of these studies found evidence of associations with generally low concentrations of arsenic (e.g., <100 μg/L arsenic in drinking water, but also including <20 μg/L in drinking water [e.g., (Wasserman et al., 2014)]. There is coherence with some of the evidence of effects on social, behavioral, and emotional effects, motor effects, and developmental delays. Some inconsistencies across these developmental neurocognitive effects studies may be due in part to variations in the age of assessment of the exposure and outcome, though this explanation cannot be confirmed. There may be other unexplained inconsistencies. There is some imprecision in the observed results, as some studies have large confidence intervals that include the null.

There is slight evidence for an association between arsenic exposure and social, behavioral, and emotional effects based on 21 medium or high confidence studies across diverse geographic regions and using different types of exposure biomarkers. Four case-control studies examined autism, with unexplained inconsistency of findings across these studies. Fourteen cross-sectional and cohort studies of other behavioral and emotional endpoints provide some evidence of adverse or suggestive adverse effects of arsenic, though there is also some unexplained inconsistency. There is coherence with the evidence for developmental neurocognitive effects and some of the evidence for motor effects as well as general developmental delays. There is some imprecision in the observed results, as some studies have large confidence intervals that include the null. There is slight evidence for an association between arsenic exposure and motor effects based on 15 medium or high confidence studies. Some studies examining populations in different countries representing a range of exposure levels and using varied exposure and outcome assessment metrics report adverse or suggestive adverse effects. Some differences in results may be due to timing of exposure or outcome ascertainment, though this explanation cannot be confirmed. There may be other unexplained inconsistency. There is coherence with the evidence for developmental neurocognitive effects and some of the evidence for social, behavioral, and emotional effects as well as developmental delays. There is some imprecision in the observed results, as some studies have large confidence intervals that include the null.

There is slight evidence for an association between arsenic exposure and developmental delays based on three medium or high confidence studies. Two of these studies provide evidence of a dose-response gradient (Hsueh et al., 2022; Hsieh et al., 2014). There is coherence with the evidence for developmental neurocognitive effects and some of the evidence for social, behavioral, and emotional effects and motor effects. There is some imprecision in the observed results, as some studies have large confidence intervals that include the null.

Overall, the currently available evidence indicates that iAs exposure likely causes neurodevelopmental effects in humans given sufficient exposure conditions. This conclusion is based on studies of humans that assessed exposure levels of <100 μg/L (including <20 μg/L) primarily showing developmental neurocognitive effects, and, to a lesser degree, social, behavioral, and emotional effects, motor effects, and developmental delays. Therefore, developmental neurocognitive effects will be considered for dose-response analysis (see Section 4.5).

Table 3-9 Evidence profile table for epidemiological evidence on iAs and neurodevelopmental effects

Evidence stream summary and interpretation
Evidence from studies of exposed humans
Studies | Summary of key findings | Factors that increase certainty | Factors that decrease certainty | Evidence synthesis judgment(s)
Developmental neurocognitive deficits; 45 medium or high confidence studies | Evidence from studies of varying design (cohort, cross-sectional, cohort) evaluating populations chronically exposed to a range of arsenic levels, report generally consistent evidence of cognitive deficits across diverse populations and with a variety exposure and outcome assessment methods. | - Studies are medium or high confidence.; - Consistency – across multiple geographic regions, exposure assessment metrics, and outcome metrics; - Coherence – with some evidence from social, behavioral, and emotional effects; motor effects; and developmental delays | - Imprecision – some studies with large confidence intervals including the null; - Unexplained inconsistency –for some studies in the evidence base | ⊕⊕⊙; Moderate
Social, behavioral, and emotional effects; 21 medium or high confidence studies | Two of four case-control studies identified an association with autism. With regard to other behavioral and emotional endpoints, varied study designs across different populations observed some associations with both internalizing and externalizing behaviors. | - Studies are medium or high confidence.; Coherence – with developmental neurocognitive and some evidence from motor effects and developmental delays | - Unexplained inconsistency –for some studies in the evidence base; - Imprecision – some studies with large confidence intervals including the null | ⊕⊙⊙; Slight
Motor effects; 15 medium or high confidence studies | Most studies from diverse regions covering a range of exposure levels identified an association between arsenic and adverse effects on motor skills and scores. | - Studies are medium or high confidence.; Coherence – with developmental neurocognitive effects and some evidence from social, behavioral, and emotional effects; and developmental delays | - Unexplained inconsistency –for some studies in the evidence base; - Imprecision – some studies with large confidence intervals including the null | ⊕⊙⊙; Slight
Developmental delays; 3 medium or high confidence studies | A small evidence base of studies using nail and urinary biomarkers in Taiwan identifies associations between arsenic exposure and developmental delays. | - Studies are medium or high confidence.; - Dose-response gradient – observed in two of three studies.; - Coherence – with developmental neurocognitive effects and some evidence from social, behavioral, and emotional effects and motor effects | - Imprecision – some studies with large confidence intervals including the null | ⊕⊙⊙; Slight

## 3.3 HAZARD CONSIDERATIONS FOR DOSE-RESPONSE ANALYSIS

To address the extensive arsenic evidence base, an exposure-response screening-level approach was developed (Hobbie et al., 2020) and applied to available dose-response data sets to help prioritize health outcomes for hazard identification and dose-response analysis. The results of the screening-level analysis provided relative risk estimates for a broad set of health outcomes potentially useful for cost-benefit considerations in addition to identifying those endpoints that support multiple-study dose-response meta-analyses. Screening-level analyses identified diseases of the circulatory system (DCS) and diabetes as health effects with sufficient data for further analysis using the Bayesian dose-response meta-analysis approach. Diabetes, fetal, newborn, and infant health outcomes, and neurodevelopmental effects were also considered for further analysis based on those endpoints’ utility for cost-benefit analyses that could be performed by EPA. As the result of this screening analysis of NRC Tier 1 and Tier 2 adverse health outcomes [see Section 5.1 of the Protocol, link provided in Appendix A and (NASEM, 2019)], EPA ultimately decided to focus on six adverse health outcomes for hazard identification and dose-response analysis in this assessment. Table 3-10 lists these six adverse health outcomes for which there is robust or moderate epidemiologic evidence that demonstrates (or indicates) inorganic arsenic causes (or likely causes) human health effects^24^ and were prioritized for dose-response analysis.

Table 3-10 Hazard identification evidence judgment summary

Health outcome category | NRC tier | Evidence judgments | Measures considered in different studies
Bladder cancer | 1 | Accepted hazard | Bladder cancer mortality; All urinary cancer; Bladder cancer; Urinary transitional cell carcinoma; Urothelial carcinoma
Lung cancer | 1 | Accepted hazard | Lung cancer mortality; Lung adenocarcinoma; Lung cancer; Other lung cancer histopath types; Squamous cell carcinoma
Diabetes | 2 | Evidence demonstrates | Diabetes mortality; Type 2 diabetes
Diseases of the circulatory system | 1 & 3 | Evidence demonstrates | IHD; IHD mortality; CVD; CVD mortality; Cerebrovascular disease and stroke; Cerebrovascular disease and stroke mortality; Hypertension; Atherosclerosis; Electrocardiogram abnormalities; Circulatory markers of cardiovascular disease
Fetal, newborn, and infant health outcomes | 2 & 3 | Evidence indicates | Fetal & infant mortality; Birthweight; Prematurity; Fetal growth; Postnatal growth
Neurodevelopmental effects | 2 | Evidence indicates | Developmental neurocognitive effects; Social, behavioral, and emotional effects; Motor effects; Developmental delays

When the toxicological database is limited to laboratory studies or when there are limited high-quality epidemiology studies available, the RfD and CSF will often be derived from a single POD, generally a BMDL, that is estimated from the best individual study. However, when multiple epidemiological studies of suitable quality are available (i.e., medium or high confidence), dose-response meta-analyses can increase the precision of the estimated POD (U.S. EPA, 2022) and the POD is more robust given it is based on multiple studies rather than a single study. Given the extensive epidemiologic database for iAs, both noncancer and cancer values could confidently be derived from high and medium confidence studies. Traditional reference doses were derived for noncancer endpoints, whereas dose-response slopes were derived from the probabilistic analyses for noncancer and cancer endpoints alike. Both the RfD and dose-response slopes were deemed useful after consulting with EPA Program Offices as they support regulator activities and benefit-cost analyses.

Section 4.3 focuses on dose-response meta-analyses of bladder cancer, lung cancer, diseases of the circulatory system (DCS) and diabetes. These dose-response meta-analyses allowed for estimates of risks above and below the RfD, as well as CSF estimates that are based on more than one POD. Dose-response analyses for fetal, newborn, and infant health outcomes and neurodevelopmental effects are featured Sections 4.4 and 4.5. For several of the outcomes in Table 3-10, epidemiological data exist for exposures below 100 μg/L drinking water or an equivalent dose, and a validated PK model (described in Section 3.1) is available to facilitate improved dose estimation and comparisons among studies. As discussed in the EPA arsenic assessment protocol (Appendix A, page 5-9), the NRC recommended focusing on studies that involved drinking water exposures of 100 μg/L and below. Thus, in Section 4, EPA explores dose-response below 100 μg/L exposures and develops risk estimates across the array of health effects. Note that when exposure levels higher than 100 μg/L were included in studies, these doses were not excluded from dose-response analyses. Then, consistent with the NRC recommendations, risk-specific doses are derived “to address the needs of analyses that would typically use a reference dose (RfD) “… to facilitate efforts to evaluate cumulative risks posed by exposure to multiple chemicals, conduct risk–benefit assessments, or to conduct other comparative analyses” (NRC, 2013).

### 3.3.1 Mechanistic Observations and Biological Plausibility

Mode of action (MOA) analyses conducted by EPA support the estimated cancer risk results (see Appendix A in the Protocol document (link to protocol)). Briefly, EPA conducted MOA analyses to characterize MOAs associated with arsenic exposure, focusing on MOAs common to multiple adverse health effects versus tissue-specific descriptions. Mechanisms of arsenic-associated disease induction are complex and appear interrelated and are likely involved in both cancer and noncancer disease outcomes. In their analyses EPA focused on seven MOAs: 1) Reactive oxygen species (ROS) generation and oxidative stress responses; 2) As(III) binding to thiol groups and inhibition of key enzymes; 3) As(V) inhibition of oxidative phosphorylation (As[V] structural analog of phosphate); 4) Cell cycling and damage repair impairment; 5) Epigenetics; 6) Endocrine disruption; and 7) Cytotoxicity and regenerative proliferation. Of these, “reactive oxygen species (ROS) generation and oxidative stress responses” has been shown to be a relevant mode of action for multiple arsenic-induced diseases including cardiovascular disease, diabetes, liver disease, lung cancer, bladder cancer, neurotoxicity, nonmalignant respiratory disease, pregnancy outcomes, renal disease, skin cancer, and skin lesions.

Arsenic metabolism in mammals involves cascades of oxidation-reduction (redox) reactions that deplete cellular thiols involved in maintaining cellular redox balance, produce trivalent methylated species, and the generate ROS. For this reason, it biologically plausible that ROS mediated adverse health effects may result following exposure to inorganic arsenic (Kitchin and Conolly, 2010; Jomova et al., 2011; Flora, 2011). Perturbation of redox balance though ROS generation [e.g., formation of superoxide, H_2_O_2_, hydroxyl radical) and depletion of antioxidant defenses (e.g., glutathione (GSH) superoxide dismutase) (Kitchin and Conolly, 2010; Jomova et al., 2011; Flora, 2011; De Vizcaya-Ruiz et al., 2009). A variety of oxidative stress markers have been measured in in vitro cell systems in the low μM range, and in animal studies in the low mg/kg-day ranges (0.5–1.7 mg/kg) (see Appendix A, Section A.3, Table A-4 in the Protocol document (link to protocol)).

For each of the cancer and noncancer health outcomes associated with arsenic exposure analyzed in this section: cancer (e.g., lung, bladder), IHD, diabetes, pregnancy outcomes, and developmental neurocognitive, the specific molecular initiating events (MIEs) and subsequent Key Events (KEs) may differ, but they follow a similar general pattern: the generation of ROS, depletion of antioxidant defenses, and perturbation of cellular redox balance. Subsequent KEs in these varied but related MOAs involve changes in protein expression and enzyme activity, lipid oxidation, DNA damage, changes in gene expression and cell signaling. For instance, alterations in protein expression levels have been observed in multiple tissue types. While observations of increased protein expression levels related to antioxidant defense (e.g., Cu/Zn superoxide dismutase [SOD], nuclear factor [erythroid-derived 2]-like 2 [Nrf2]) (Zheng et al., 2012; Zhao et al., 2012; Li et al., 2011) and DNA repair (e.g., DNA polymerase β) (Snow et al., 2005) may occur across multiple cell types, other observations of elevated protein levels may be cell-specific (e.g., platelet endothelial cell adhesion molecule) (Straub et al., 2008).

### 3.3.2 Cancer

Mechanistic evidence from human in vitro cell models, specifically human urothelial cells, shows that iAs produced ROS may also activate RAS signaling and activation of ErbB2 receptor (Eblin et al., 2007; Eblin et al., 2009), activate growth factor and cytokine activation (Escudero-Lourdes et al., 2012), damages DNA and promotes p53 dysregulation (Wnek et al., 2009; Sun et al., 2014; Kojima et al., 2009; Escudero-Lourdes et al., 2012; Drobna et al., 2003), and perturbs DNA repair enzymes such as OGG1 and p53 (Wnek et al., 2009).

Evidence suggests that persistent inorganic arsenic exposure may result in prolonged activation of the Nrf2 transcription factor pathway (Lau et al., 2013). The Nrf2 pathway is activated by oxidative stress and plays a key role in antioxidant defense; however, prolonged activation of the Nrf2 pathway can lead to sustained cell growth and is associated with cancer in several tissues (e.g., breast, bladder, skin) (Lau et al., 2013). Data indicate that inorganic arsenic exposure may mimic constitutive Nrf2 activation found in several tumor types (Lau et al., 2013). Like observations of prolonged Nrf2 activation, data also suggest that inorganic arsenic promotes stabilization of the transcription factor HIF-1α, thus leading to prolonged transcriptional activation of downstream targets (e.g., vascular endothelial growth factor [VEGF]) (Li et al., 2014). Downstream targets of HIF-1α can play a key role in malignant transformation and carcinogenesis by promoting angiogenesis, dedifferentiation, and glycolysis (Li et al., 2014).

Prolonged HIF-1α activation following inorganic arsenic exposure is dependent on increases in ROS produced primarily by the mitochondrial electron transport chain, possibly through inorganic arsenic activation of NADPH oxidase at the cell surface (Li et al., 2014). Together with data on Nrf2 activation, evidence that inorganic arsenic perturbs HIF-1α transcriptional activity via ROS production provides insight on how subsequent changes at the cellular or tissue/organ levels may be quite distinct despite being initiated through a common MOA. These data taken together add to the weight of evidence that it is biologically plausible that inorganic arsenic exposure increases the risk for human bladder and lung cancer.

10 This terminology is consistent with the latest International Classification of Disease-10 (https://icd.who.int/browse10/2016/en#/).

11 CHD is largely synonymous with IHD but has no specific ICD code; studies that use the term CHD to define cases are included in the IHD sections of this assessment.

12 The Moon et al. (2017b) meta-analysis is discussed further in Appendix C.1.2 (Ischemic Heart Disease (IHD) Incidence; Comparison of Studies Selected for EPA Dose-Response Meta-Analysis and Studies Used in Earlier Meta-Analyses). EPA’s Bayesian meta-regression analyses of CVD and IHD outcomes are summarized in Section 4.3.7. There are important differences between the Moon et al. (2017b); Moon et al. (2012), and the EPA meta-analyses of CVD and IHD outcomes with respect to study selection, data adjustments/pre-analysis and modeling methods.

13 Moon et al. (2012); Moon et al. (2017b) reported that “compared with 10 mg/L, the estimated pooled relative risks [95% confidence interval (CI)] for 20 mg/l water arsenic, based on a log-linear model, were 1.09 (1.03, 1.14) (N=2) for CVD incidence, 1.07 (1.01, 1.14) (N=6) for CVD mortality, 1.11 (1.05, 1.17) (N=4) for CHD incidence, 1.16 (1.07, 1.26) (N=6) for CHD mortality, 1.08 (0.99, 1.17) (N=2) for stroke incidence and 1.06 (0.93, 1.20) (N=6) for stroke mortality.”

14 The Moon et al. (2017b) meta-analysis is discussed further in Appendix C.1.2 (Ischemic Heart Disease (IHD) Incidence; Comparison of Studies Selected for EPA Dose-Response Meta-Analysis and Studies Used in Earlier Meta-Analyses). EPA’s Bayesian meta-regression analyses of CVD and IHD outcomes are summarized in Section 4.3.7. There are important differences between the Moon et al. (2012); Moon et al. (2017b) and the EPA meta-analyses of CVD and IHD outcomes with respect to study selection, data adjustments/pre-analysis and modeling methods.

15 Moon et al. (2012); Moon et al. (2017b) reported that “compared with 10 μg/L, the estimated pooled relative risks [95% confidence interval (CI)] for 20 μg/l water arsenic, based on a log-linear model, were 1.09 (1.03, 1.14) (N=2) for CVD incidence, 1.07 (1.01, 1.14) (N=6) for CVD mortality, 1.11 (1.05, 1.17) (N=4) for CHD incidence, 1.16 (1.07, 1.26) (N=6) for CHD mortality, 1.08 (0.99, 1.17) (N=2) for stroke incidence and 1.06 (0.93, 1.20) (N=6) for stroke mortality.”

16 Fibroblast growth factor 2 (FGF-2) can be used in Matrigel to model angiogenesis in mice (Claffey et al., 2001).

17 The term, “sufficient exposure conditions,” is discussed and defined for the identified health effects in the dose-response analysis in Section 4.

18 The SHFS is an extension of the Strong Heart Study (SHS), a population-based study of American Indian adults in which relatives of the SHS participants were recruited.

19 A statistically significant association between iAs exposure and diabetes mortality was only observed in female but not in male individuals in this study.

20 The term, “sufficient exposure conditions,” is discussed and defined for the identified health effects in the dose-response analysis in Section 4.

21 Neurodevelopmental outcomes are discussed in Section 3.2.4.

22 The term, “sufficient exposure conditions,” is discussed and defined for the identified health effects in the dose-response analysis in Section 4.

23 The term, “sufficient exposure conditions,” is discussed and defined for the identified health effects in the dose-response analysis in Section 4.

24 Lung and bladder cancer are accepted hazard outcomes for iAs based on robust evidence and previous assessments by EPA and other health agencies and similar to four other outcomes EPA continued to prioritize these endpoints for further dose-response analysis.