# 2 LITERATURE SEARCH AND STUDY EVALUATION RESULTS

## 2.1 LITERATURE SEARCH AND SCREENING RESULTS

The database searches conducted between January 2013 and January 2019 yielded 35,964 unique studies (see Figure 2-1 and Figure 2-2). Software workflows have evolved since 2013; thus, Figure 2-1 shows the initial literature search and updates through 2015, and Figure 2-2 shows literature searches conducted from October 2015 through January 2019. Of the 35,964 studies identified, 33,337 were excluded during initial filtering and title and abstract screening, 1003 were reviewed at the full-text level. Of the 1003 screened at full-text level, 354 epidemiological studies were considered to meet PECO criteria (see Table 1-2). A literature search update conducted August 2022 yielded an additional 169 PECO relevant studies (see Figure 2-2 and Appendix B.3), and studies with hazard and/or dose-response utility were integrated. An additional literature search update focusing on neurodevelopmental effects, conducted in August 2024, identified 15 PECO relevant studies for consideration in in meta-analysis. Literature search and screening results are summarized in HAWC.

## 2.2 STUDY EVALUATION RESULTS

The study evaluations of the available epidemiological studies for bladder cancer, lung cancer, DCS, diabetes, fetal, newborn, and infant health outcomes, and neurodevelopmental effects are summarized in HAWC (https://hawc.epa.gov/assessment/100500243/). The evidence synthesis analysis of studies with health outcome judgment of medium or high confidence are discussed in Section 3.2.

Figure 2-1 Literature search and screening flow diagram for inorganic arsenic (initial database search and updates through 2015)

^1^ Initial results only

^2^ Studies may be in multiple groups

Figure 2-2 Literature search and screening flow diagram for inorganic arsenic (October 2015 to January 2019; 2022 search update; 2024 search update focused on neurodevelopmental effects)

^1^15 neurodevelopmental studies identified in August 2024 search update

^2^Studies may be in multiple groups