# 1 BACKGROUND INFORMATION AND ASSESSMENT METHODS

## 1.1 INTRODUCTION

The inorganic arsenic assessment (iAs) is being developed by the Integrated Risk Information System (IRIS) Program at the request of U.S. Environmental Protection Agency’s (EPA) Office of Land and Emergency Management (OLEM), Office of Water (OW), and regions 1–10 (see December 2018 IRIS Program Outlook (https://www.epa.gov/sites/production/files/2018-12/documents/iris_program_outlook_december_2018.pdf)). This assessment evaluates the publicly available studies on iAs in order to identify its adverse health effects and to characterize exposure-response relationships. In addition to use by OLEM and OW, this assessment can be used by other EPA National Program and Regional offices, states and local health agencies, Tribes, other federal agencies, international health organizations, and other external stakeholders.

A link to the updated problem formulation and systematic review protocol for the iAs assessment is contained in Appendix A. The protocol outlines the updated scoping and problem formulation efforts relating to this assessment. The protocol also lays out the systematic review and dose-response methods used to conduct this review. This updated problem formulation and systematic review protocol was released in 2019 for public comment and review by NASEM (2019). NASEM recommendations and public comments were considered in preparing the draft assessment and protocol amendments (see Protocol, Section 6, for a description of the amendments).

This assessment was released for public comment on October 16, 2023, and comments were due on December 16, 2023. BMD Model Code and Modeling Results were released for public comment on December 29, 2023, and comments were due January 16, 2024. The public comments are available on Regulations.gov in Docket EPA-HQ-ORD-2012-0830. A summary and EPA’s disposition of the comments received is included in Appendix F. This assessment was peer reviewed by independent expert scientists external to EPA convened by the EPA Science Advisory Board (SAB). Peer-review meetings were held on January 5, 2024; January 24–26, 2024; July 8, 2024; July 16, 2024; and October 15–16, 2024. The report of the review of the EPA’s Draft Toxicological Review of Inorganic Arsenic, dated November 19, 2024, is available on the IRIS website. A summary and EPA’s disposition of the comments received is included in Appendix F.

## 1.2 BACKGROUND INFORMATION ON INORGANIC ARSENIC

Section 1 provides a brief overview of aspects of the physicochemical properties; sources, production, and use; environmental fate and transport; and human exposure characteristics of inorganic arsenic (iAs, CASRN 7440-38-2). This overview is not intended to provide a comprehensive description of the available information on these topics but to provide contextual information for the assessment.

## 1.3 PHYSICAL AND CHEMICAL PROPERTIES

Elemental arsenic, or metallic arsenic, is a steel grey solid with chemical and physical properties intermediate between a metal and nonmetal (IARC, 2009). Arsenic can exist in four oxidation states: −3, 0, +3, or +5. Because of its reactivity, elemental arsenic (oxidation state 0) is rarely found in the environment (U.S. EPA, 2006; ATSDR, 2007). Instead, arsenic is often found combined with other elements and commonly exists in biologic systems as: arsenite (AsIIIO_3_⁻^3^), arsenate (AsvO_4_⁻^3^), arsenide (As⁻^3^), and organic arsenic compounds (As-C covalent bond). The IRIS assessment is limited to inorganic arsenic, defined as arsenite and arsenate salts and arsenoxides. For the purposes of this document, the term arsenic refers to inorganic arsenic unless otherwise specified. Arsenate and arsenite compounds and alkylated arsenic species are used commercially. Inorganic arsenic predominates in environmental media (air, water, soil) and commercial uses and it is more toxic than organic arsenic (U.S. EPA, 2006; OEHHA, 1996; ATSDR, 2007). The chemical and physical properties of arsenic are listed in Table 1-1.

Table 1-1 Chemical and physical properties of arsenic and selected inorganic arsenic compounds (ATSDR, 2000; Budavari, 1989)

| Arsenic | As_2_O_3_ | As_2_O_5_ | NaAsO_2_ | Na_2_HasO_4_
CAS No. | 7440-38-2 | 1327-53-3 | 1303-28-2 | 7784-46-5 | 7778-43-0
Oxidation state | 0 | +3 | +5 | +3 | +5
Molecular weight | 74.9 | 197.8 | 229.8 | 129.9 | 185.9
Synonyms | Metallic arsenic, grey arsenic | Arsenic trioxide, arsenolite, white arsenic (+3) | Arsenic pentoxide, arsenic acid anhydride (+5) | Sodium arsenite (+3) | Disodium arsenate (+5)
Physical state (25°C) | Solid | Solid | Solid | Solid | Solid
Boiling point (°C) | 613 (sublimes) | 465 | – | – | –
Melting point (°C) | 817 @ 28 atm | 312 | 315 (decompose) | – | 86.3
Density (g/cm^3^) | 5.7 | 3.7 | 4.3 | 1.8 | 1.8

– No data available.

## 1.4 SOURCES, PRODUCTION, AND USE

Inorganic arsenic is widely distributed throughout the Earth’s crust and is present in more than 200 mineral species (IARC, 2009; Health Canada, 2006; ATSDR, 2007). Natural sources of inorganic arsenic result in naturally occurring, or “background,” levels of inorganic arsenic in soil. Natural sources can also contribute to inorganic arsenic in water, particularly groundwater from wells in arsenic-rich geological formations. Volcanic activity releases, volatilization, and dusts are some natural sources of inorganic arsenic released in the atmosphere. It is estimated that approximately one-third of atmospheric inorganic arsenic comes from natural sources (IARC, 2012).

Inorganic arsenicals are used in the manufacturing and processing of several products. The arsenic metalloid is used for hardening copper and lead alloys (HSDB, 2005). It is also used in glass manufacturing as a decolorizing and refining agent, as a component of electrical devices in the semiconductor industry, and as a catalyst in the production of ethylene oxide. Arsenic compounds are used as a mordant in the textile industry, for preserving hides, as medicinals, pesticides, pigments, and wood preservatives. The production of chromate copper arsenate, a wood preservative, accounts for approximately 90% of the domestic arsenic consumption (ATSDR, 2007). However, production of this preservative is being phased out since 2003 (ATSDR, 2007). The uses of inorganic arsenical compounds (e.g., lead arsenate) as pesticides were voluntarily cancelled by the industry during late 1980s and early 1990s. The majority of organoarsenicals are used on cotton and turf as herbicides. Disodium methanearsenate (DSMA), monosodium methanearsenate (MSMA), and calcium methanearsenate (CAMA) continue to be used as contact herbicides.

### 1.4.1 Environmental Fate and Transport: Soil

In soil there are many biotic and abiotic processes controlling arsenic’s overall fate and environmental impact. Arsenic in soil exists in various oxidation states and chemical species, depending upon the soil pH and oxidation-reduction potential (ATSDR, 2007). Arsenic is largely immobile in agricultural soils and tends to remain in upper soil layers (ATSDR, 2007). However, reducing conditions form soluble mobile forms of arsenic and leaching is greater in sandy soil than in clay loam (ATSDR, 2007). Mobility of arsenicals is typically very low to intermediate, and sorption is higher in soils with higher percentage of clay or with more iron or aluminum content (U.S. EPA, 2006).

### 1.4.2 Environmental Fate and Transport: Water

Transport and partitioning of arsenic in water depends upon the chemical form of the arsenic and on interactions with other materials present (ATSDR, 2007). Under normal conditions in water, arsenic is present as soluble inorganic As^V^ because it is thermodynamically more stable in water than As^III^. Soluble forms may be carried long distances through rivers, but arsenic may also be adsorbed from water onto sediments or soils, especially clays, iron oxides, aluminum hydroxides, manganese compounds, and organic material (Welch et al., 1988; U.S. EPA, 1982). Groundwater arsenic concentrations are usually controlled by adsorption rather than by mineral precipitation under oxidizing and mildly reducing conditions (ATSDR, 2007).

### 1.4.3 Environmental Fate and Transport: Air

High temperature processes, such as coal and oil combustion, smelting operations, and refuse incineration, contribute to most of the anthropogenic arsenic emitted to the atmosphere (Pacyna, 1987). These fine particles, with a mass median diameter of about 1 μm, can reside in the atmosphere for about 7–9 days and be transported thousands of kilometers by wind and air currents until they are returned to earth by wet or dry deposition (Pacyna, 1987). Atmospheric fallout can also be a significant source of arsenic in coastal and inland waters near industrial areas (ATSDR, 2007).

## 1.5 OCCURRENCE IN THE ENVIRONMENT

Arsenic naturally comprises ~ 3.4 parts per million (ppm) of the earth’s crust, where it is the twentieth most abundant element (ATSDR, 2007). Arsenic leaches from natural weathering of soil and rock into water and low concentrations of arsenic are found in water, food, soil, and air. However, industrial activities such as coal combustion and smelting operations release higher concentrations of arsenic to the environment (Adams et al., 1994). The highest background arsenic levels found in the environment are in soils, with concentrations ranging from 1 to 40 ppm (ATSDR, 2007). Food typically contains total arsenic concentrations of 20 to 140 parts per billion (ppb), with inorganic arsenic levels being much lower than organic arsenic levels (ATSDR, 2007). The majority of surface and ground waters contain less than 10 μg/L^3^ (although levels of 1,000–3,400 μg/L have been reported, especially in areas of the western United States) (DeSimone et al., 2015; ATSDR, 2000). The average arsenic content in drinking water in the United States (U.S.) has been estimated to be 2 μg/L with approximately 12% of the water supply from surface water in central portions of the U.S. and 12% of groundwater sources in western portions of the U.S. exceeding 20 μg/L (DeSimone et al., 2015; ATSDR, 2007). Mean arsenic concentrations in ambient air have generally been found to range from 1 to 2,000 ng/m^3^ (Wai et al., 2016; ATSDR, 2007).

### 1.5.1 Potential for Human Exposure and Populations with Potentially Greater Exposure

Oral exposure is the primary route of environmental exposure to inorganic arsenic, occurring through dietary intake of contaminated food or drinking arsenic-contaminated water. This assessment focuses on oral exposure based on agency needs.

Inorganic arsenic is found in meats, poultry, dairy products, and cereal (IARC, 2009). High levels of inorganic arsenic have been found in rice cereals Signes-Pastor et al. (2016) and rice cereal is the largest source of inorganic arsenic for four- to 24-month-olds Shibata et al. (2016). Elevated exposures to arsenic from rice products and other foods commonly consumed by infants during to the transition to solid foods represents an important source of exposure during a critical window of development (Signes-Pastor et al., 2018). Inorganic arsenic has also been found in fruit juices and infant rice cereal and the FDA currently recommends an “action level” of 10 ppb for inorganic arsenic in apple juice (FDA, 2013) and 100 ppb in infant rice cereal (FDA, 2016; FDA, 2020). In young children, oral exposure to inorganic arsenic may also occur through hand-to-mouth activity with contaminated soil. Naturally occurring levels of inorganic arsenic in soil are approximately 5 mg/kg but can range from 1 mg/kg to 40 mg/kg depending upon the geological formation. In addition, certain foods, especially rice and rice-derived sweeteners used in organic food products, grown in soil containing inorganic arsenic have been shown to concentrate arsenic (Jackson et al., 2012; Pogoson et al., 2021).

During early life, inorganic arsenic and its methylated metabolites readily pass the placental barrier, resulting in potentially elevated fetal exposure (Vahter, 2009; Hall et al., 2007; Concha et al., 1998). With advancing gestation, the efficiency of maternal arsenic methylation increases, resulting in lower exposure of the fetus to inorganic arsenic and MMA (Vahter, 2009; Li et al., 2008; Gardner et al., 2011; Concha et al., 1998). However, if maternal exposure is high, maternal arsenic methylation could be inhibited, resulting in elevated exposure of the fetus to inorganic arsenic and MMA (Vahter, 2009). The transfer of arsenic into breast milk is limited, and breastfeeding, which results in efficient methylation of arsenic and contains choline, antioxidants, and other protective components, can partially shield infants from some of the adverse impacts of arsenic exposure (Vahter, 2009; Fängström et al., 2008; Concha et al., 1998). However, formula-fed infants experience elevated exposure due to the inorganic arsenic content of formula powder as well as arsenic-contaminated drinking water used for reconstitution (Carignan et al., 2015).

Surface water generally contains less than 10 μg/L of arsenic; however, concentrations can vary depending upon proximity to anthropogenic or natural sources of arsenic. Levels of inorganic arsenic in water can exceed 1,000 μg/L in regions with arsenic-rich geological formations. For populations living in these regions, drinking groundwater or well water contaminated with arsenic could contribute to inorganic arsenic exposure (IARC, 2009). In addition, preparation of food in water containing inorganic arsenic could also increase arsenic content of food. Exposure to high levels of inorganic arsenic in drinking water has been documented in several regions of the world, including China, Taiwan, Bangladesh, and South America. In the United States, the average inorganic arsenic content of drinking water is 2 μg/L, although 12% of water supplies from surface water in the central United States and 12% of ground water sources in the western United States exceed 20 μg/L (DeSimone et al., 2015; ATSDR, 2007).

Some studies in this assessment were conducted in areas with fairly high levels of arsenic contamination in groundwater while others cover populations with lower levels of potential exposure. However, not all epidemiological studies cited in this assessment clearly report external exposure levels in environmental media for the populations under investigation and therefore it is not feasible to contextualize all studies with respect to environmental exposure levels. To help provide context, Figure 1-1 illustrates historical exposure levels across the world (Schwarzenbach et al., 2010). In Section 3.2, the country where each epidemiology study was conducted is presented in data visualizations (i.e., forest plots) to provide information on relative environmental exposure levels. For summary purposes, higher exposures are considered to be from countries such as Bangladesh, China, and Chile, while lower exposures include the United States, Mexico, and Denmark. Supplemental pivots for for scenarios with maximum arsenic exposures <100 μg/L in drinking waterare described in 1.6.3 below.

Figure 1-1 Arsenic levels in groundwater across the world (Schwarzenbach et al., 2010)

Source: https://pubs.acs.org/doi/10.1021/es702859e (https://gcc02.safelinks.protection.outlook.com/?url=https%3A%2F%2Fpubs.acs.org%2Fdoi%2F10.1021%2Fes702859e&data=05%7C02%7CLee.JaniceS%40epa.gov%7C8a922612d2b1477ffc0508dcfe5c5ac3%7C88b378b367484867acf976aacbeca6a7%7C0%7C0%7C638664919839036498%7CUnknown%7CTWFpbGZsb3d8eyJFbXB0eU1hcGkiOnRydWUsIlYiOiIwLjAuMDAwMCIsIlAiOiJXaW4zMiIsIkFOIjoiTWFpbCIsIldUIjoyfQ%3D%3D%7C0%7C%7C%7C&sdata=79CYbH%2BRBBgR404kRbz%2BQ56AYfhakohDRWnqbRl%2FHUc%3D&reserved=0). Further permissions related to the figure should be directed to the ACS.

For the general population, inhalation of inorganic arsenic from air is not a primary route of exposure. Exposures range from 0.02–0.6 μg/day in areas without substantial inorganic arsenic emissions from anthropogenic sources (WHO, 2000). Higher levels of inhalation exposure to inorganic arsenic are observed in more “polluted” areas, include areas near smelting, coal-fired power plants, pressure-treated wood, glass manufacturing, and electronics industry. Both direct inhalation and consumption and inhalation of re-entrained dust can be of concern. WHO (2000) reports that near emission sources concentrations of airborne arsenic can exceed 1 μg/m^3^. Smokers can be exposed up to 10 μg/day of arsenic due to the natural absorption of arsenic from soil by tobacco plants (IARC, 2009; ATSDR, 2007). Inhalation is the principal route of exposure in occupational exposure settings. Industries with potential inorganic arsenic exposure include smelting, coal-fired power plants, pressure-treated wood, glass manufacturing, and electronics industry. It is likely that ingestion and dermal exposure occurs simultaneously in certain occupational settings (IARC, 2009). Since oral exposure is the primary route of exposure for the general population, inhalation exposure to inorganic arsenic was not evaluated further in the main analysis. However, the impact consideration of inhalation exposure has on risk estimation was investigated in sensitivity analyses (Appendix C.1.2). In addition, the primary agency need is oral, inhalation studies are mainly occupational studies, and the bulk of the new epidemiological studies concern oral exposure.

Dermal exposure is a potential route of exposure for inorganic arsenic, but it is generally accompanied by either inhalation or oral exposure; either of which would be the more predominant exposure route. Inorganic arsenic is found in soils, but due to the formation of insoluble complexes with iron, aluminum, or magnesium oxide, it is poorly absorbed in humans (ATSDR, 2007). Exposure through bathing in contaminated water is a possibility and may contribute to effects, but there are no studies to quantify the dermal exposure. Dermal exposure may play a larger part in effects to the skin. In vitro studies using artificial human skin indicates that the skin would retain 1%–10% of the applied dose (Bernstam et al., 2002). Although dermal exposure may add to the overall exposure, it is not a focus of this assessment because it represents minimal exposure compared with oral or inhalation exposure, that there are no studies that specifically evaluate effects after dermal exposure, and that there are no physiologically based pharmacokinetic (PBPK) models in humans to convert from oral to dermal exposure precludes consideration of dermal exposure in this assessment.

## 1.6 SUMMARY OF ASSESSMENT METHODS

Section 1.6 summarizes the methods used for developing this assessment. As outlined in the Updated Problem Formulation and Protocol for the Inorganic Arsenic IRIS Assessment (link provided in Appendix A), epidemiological evidence is the focus of this assessment given the abundance of epidemiological evidence and preference for using human data over animal data when available (NRC, 2013; NASEM, 2019). With respect to the animal data, most adult laboratory animal models appear to be less susceptible to inorganic arsenic than humans when comparative information is available (Vahter and Norin, 1980; Vahter, 1994; Lynch et al., 2017a, b). Interspecies metabolism differences likely explain the differences in toxicity between animals and humans, with animals requiring higher doses to reach internal doses comparable to those observed in humans. Thus, analysis of the epidemiological evidence base was the basis for prioritizing health outcomes for dose-response analysis. Mechanistic evidence has also been extensively considered during the course of preparing this assessment, especially in the context of addressing differences in anticipated response among humans (e.g., between children and adults) and to inform decisions about the anticipated shape of the dose-response relationship. Ultimately, the epidemiological evidence was comprehensive and sufficient to inform these judgments. This approach was supported by the NRC (2013) and NASEM (2019) and is consistent with assessments by others (TCEQ, 2017; EFSA, 2009; ATSDR, 2007).

### 1.6.1 Literature Search and Screening

The detailed search approach, including the query strings are provided in Section 3.3 and Appendix B of the protocol. Populations, Exposures, Comparators, and Outcomes (PECO) criteria (see Table 1-2) were used to identify the evidence that addresses the specific aims of the assessment and to focus the literature screening, including study inclusion/exclusion. PBPK models are considered to meet PECO criteria. The initial PECO for inorganic arsenic was based on recommendations presented in the 2013 National Research Council Critical Aspects of EPA’s Integrated Risk Information System Assessment of Inorganic Arsenic (NRC, 2013). Changes in the PECO over time are reflected in Table 1-2, reflecting an ascertained focus on epidemiological studies and prioritized health outcomes (bladder cancer, lung cancer, DCS, diabetes, fetal, newborn, and infant health outcomes, and neurodevelopmental effects) [see Section 3.2 for more details on the focus of these health outcomes and (NASEM, 2019)]. The literature search was first conducted in 2012 and regular updates were performed (see below for additional details). The literature search queries the following databases (no date or language restrictions were applied):

- PubMed (National Library of Medicine (https://www.ncbi.nlm.nih.gov/pubmed/))
- Web of Science (Thomson Reuters (https://apps.webofknowledge.com/))
- Toxline (National Library of Medicine (https://toxnet.nlm.nih.gov/cgi-bin/sis/htmlgen?TOXLINE))^4^

All literature is tracked in the U.S. EPA Health and Environmental Research Online (HERO) database (https:// https://hero.epa.gov/hero/index.cfm/project/page/project_id/2211).

Table 1-2 Populations, exposures, comparators, and outcomes (PECO) and other inclusion criteria

PECO element | Evidence
Populations | This assessment focuses on human studies only to include any population and life stage (occupational or general population, including children and other sensitive life stages or populations).
Exposures | Subchronic- or chronic -duration studies of interest provide quantitative estimates of exposure with measurements based on biomonitoring data (e.g., hair, nails, urine, or blood), drinking water exposures (μg/L), cumulative exposures (μg/m^3^*yr; μg/L*yr), and doses expressed as μg/d and μg/kgd-. Studies with episodic or acute exposures will be excluded (i.e., poisonings or other short term- exposures that last up to 30 d).; Studies using arsenicals, primarily arsenic trioxide and Fowler’s solution will be excluded because chemotherapeutic agents are not within the scope of this review. Studies using arsenide (As^3−^), an inorganic form of arsenic, also will be excluded. Exposures usually occur via the gas arsine and result in a different, distinctive toxicological profile based on binding to hemoglobin and red blood cell lysis.; This assessment focuses on oral exposure because it is the main route of exposure for the general population, it is a primary agency need, and most inhalation studies are occupational studies.
Comparators | A comparison or referent population exposed to lower levels (or no exposure/exposure below detection limits) of inorganic arsenic, or exposure to inorganic arsenic for shorter periods of time, or cases vs. controls. Exposure-response quantitative results are presented in sufficient detail (e.g., odds ratios or relative risks with associated confidence intervals, numbers of cases/controls).
Outcomes | Health outcomes of interest, based on hazard judgment, relative risk over the background exposure (RRB), and potential use for benefit-costs analysis by program offices, include bladder cancer, lung cancer, DCS, diabetes, fetal, newborn, and infant health outcomes, and neurodevelopmental effects.
Other included study types
PBPK models | Studies describing PBPK models for inorganic arsenic will be considered to meet PECO criteria.

PBPK = physiologically based pharmacokinetic.

Note: Animal and mechanistic data are considered supplemental material and not tracked as PECO relevant (see Sections 2.3.1. and 2.3.2. of the protocol, Appendix A).

In addition to evaluating studies for adherence to PECO criteria, studies containing supplemental material that did not meet PECO criteria potentially relevant to the specific aims of the assessment were inventoried during the literature screening process. Functionally, supplemental material studies were not excluded. Some studies could emerge as being critically important to the assessment and may need to be evaluated and summarized at the individual study level (e.g., certain cancer MOA or ADME studies), or might be helpful to provide context (e.g., provide hazard evidence from routes or durations of exposure not meeting the assessment PECO), Studies categorized as “potentially relevant supplemental material” included the following:

- Epidemiological studies on other health outcomes not listed in PECO.
- Toxicology: Experimental animal studies presenting original data investigating the effects of chronic exposure to iAs.
- Mode of action/mechanistic: Studies that examine the molecular and/or cellular events and alterations in system biology occurring after iAs exposure (e.g., alterations in epigenomics, genomics, oxidative stress, immune function, and endocrine disruption). Metabolites of iAs are only considered as they pertain to MOA.
- Meta-analyses that contain original analyses.
- Susceptibility: Studies that do not meet PECO-based inclusion criteria, but which include analyses of health effects relevant to the PECO that are evaluated based on potential risk modifiers (e.g., smoking, genetic polymorphisms, susceptibility due to methylation capacity, socioeconomic factors, ethnicity). Studies that identify potentially susceptible subgroups based on intrinsic factors (e.g., age, sex, genetics, health status, behaviors) and certain extrinsic factors (e.g., socioeconomic status, access to health care), studies that identify groups based on extrinsic factors, such as increased risk for exposure due to occupation or residential proximity to exposure sources, are not considered to be susceptible populations.
- ADME/pharmacokinetics (PK): Studies that examine internal dose metrics, absorption, distribution, metabolism, and excretion (i.e., PK).
- Exposure assessment: Studies that describe exposure to arsenic in the air, water, food, or through dermal contact. Includes bioavailability studies for the different media and studies that measured arsenic levels in humans (e.g., in nails, urine, blood) and studies that do not evaluate health outcomes but provide an understanding of arsenic exposures that may be associated with health effects.

The literature was screened by two independent reviewers with a process for conflict resolution, first at the title and abstract level and subsequently the full-text level. Literature inventories for PECO relevant studies and studies tagged as “potentially relevant supplemental material” during screening were created to facilitate subsequent review of individual studies or sets of studies by topic-specific experts.

Literature searches and updates were completed between 2012 and 2019. Following prioritization of the six select outcomes, another literature search was conducted in 2022. The characterization of newly identified studies from the 2022 literature search update focused on EPA’s judgment of whether studies would have a material impact on the conclusions (i.e., identified hazards or toxicity values) in the external review draft (see Table B-17 in Appendix B.3).

DCS and diabetes studies identified in the most recent literature search update (August 2022) did not undergo study evaluation because EPA already characterized the strength of the evidence base for these health outcomes to be robust (based on studies identified up to 2019) and EPA determined that these new studies would not impact the draft hazard conclusion. However, as discussed in Section 4.3, these studies were considered for dose-response utility and evaluated against criteria of particular importance for EPA’s dose-response meta-analysis approach [see the iAs Protocol (link provided in Appendix A), Section 5.1]. For DCS and diabetes, if a study from the recent literature search update made it through study selection for dose-response, it then underwent study evaluation to ensure that it was medium or high confidence. This allowed EPA to prioritize efforts for study evaluation focusing on those studies that could be considered suitable for dose-response largely based on study design characteristics (Section 1.6.5).^5^

EPA characterized the strength of the evidence base to be moderate for fetal, newborn, and infant health outcomes and neurodevelopmental effects (based on studies identified up to 2019) and studies identified in the 2022 update underwent risk of bias evaluation to determine if new studies would change the hazard conclusion and/or impact dose-response analyses. To further screen studies for dose-response utility, additional consideration was given to study type and whether the study took into account key confounding factors, such as smoking. Studies from the recent literature search update are included in the synthesis sections for fetal, newborn, and infant health outcomes and neurodevelopmental effects. An additional literature search update focusing on neurodevelopmental effects was conducted in August 2024 to identify potentially relevant studies for use in meta-analysis. This was undertaken because the 2023 draft assessment considered only a single study when determining the evidence base that did not support the derivation of a candidate RfD, and EPA’s preference is to conduct meta-analyses for all prioritized health outcomes if possible. Similar to the 2022 update, neurodevelopmental studies identified in the 2024 update underwent risk of bias evaluation and were evaluated against criteria of particular importance for EPA’s dose-response meta-analysis.

### 1.6.2 Evaluation of Individual Studies

The detailed approaches used for the evaluation of epidemiological studies used in the inorganic assessment are provided in the systematic review protocol (link provided in Appendix A, Section 3.9) and summarized in Figure 1-2. Epidemiologic studies containing hazard or dose response data were subject to risk- of- bias (RoB-) evaluations to assess aspects of internal validity of study findings based on study design and conduct for hazard identification. Key concerns are potential bias (factors that affect the magnitude or direction of an effect) and insensitivity (factors that limit the ability of a study to detect a true effect). Risk of bias for each study was evaluated across seven evaluation domains (i.e., selection, confounding, performance, attrition, detection, selective reporting bias, and other) using a tool adapted from the OHAT approach (NTP, 2013)^6^ with arsenic-specific clarifications as needed (see below and in Protocol (link provided in Appendix A)). Consistent with a consideration of the strengths and limitations in each domain, risk of bias was assessed for each study question using a rating system with four categories as follows: definitely low bias, probably low bias, probably high bias, and definitely high bias (see the iAs Protocol (link provided in Appendix A), Table 3-3). Evaluations were documented using ICF’s DRAGON and Litstream (https://www.icf-litstream.com/) and can now be found in Health Assessment Workspace Collaborative (HAWC (https://hawc.epa.gov/assessment/100500243/)). An overall study determination (see below) was based on these individual domain level judgments. Some of the key arsenic-specific evaluation considerations are described here.

#### Temporality

Temporality between the measurement of exposure and development of the outcome of interest is an important issue in epidemiologic studies. In general, cohort studies are subject to fewer concerns about temporality than other observational study designs due to their prospective nature. However, concerns for lack of temporality in other study designs such as cross-sectional, case-control, and ecological studies can be ameliorated by considering the likelihood that the concurrent exposure measurement is a reasonable proxy of a relevant etiologic period. For example, many of the available cross-sectional studies included populations that had been highly exposed to arsenic at a stable level for more than 5–10 years, which provides increased confidence regarding the suitability of concurrent measures compared with typical cross-sectional study scenarios. In addition, concurrent measurement of exposure is more appropriate for outcomes without a long latency period and analyses where reverse causation is not a concern (i.e., it is unlikely that development of the outcome would influence the measured exposure, or exposure was measured in water).

#### Ecological Studies: Unique Considerations in the Context of Arsenic

In addition to the temporality concerns discussed above, ecological studies are limited by their lack of individual-level data. In this study design, there is no access to individual-level data and the analyses produce group-level exposure-response functions. However, in the case of arsenic specifically, ecological studies can provide important information to inform causal inference due to well-defined exposure periods, limited population migration, large sample sizes, and large amount of data available helping to reduce the effects of confounding variables. Because of these unusual strengths, several ecological studies were included in the evidence synthesis. The arsenic database also includes ecological studies that function as “natural experiments.” These unique exposure scenarios, which include large exposure contrasts, are defined by a clearly identified intervention, provide a natural experiment for evaluation of health hazards. One such example is seen in southwest Taiwan where exposure through drinking water was high—500-fold higher than average drinking water concentrations in the U.S.—but that exposure ceased after drinking water interventions were implemented. Observed associations from natural experiment-ecological studies, particularly in combination with other studies using individual-level data, provide elevated confidence in the observed associations.

#### Exposure Assessment

The arsenic evidence base contains studies that utilize a variety of approaches, each with their own strengths and weaknesses. In many of these studies, individual exposure was estimated based on arsenic concentrations in drinking water without information on individual-level water intake. This approach is limited by potential nondifferential misclassification for the individual, which is expected to produce bias towards the null (i.e., attenuated effect estimates) on average. Other studies utilized biomarker measures of arsenic, such as in urine, toenail, hair, or blood. An important strength of biomarker studies is that they can better reflect the internal As dose and account for multiple potential sources/routes of exposure. However, there are some concerns with biomarker use as well. For example, the use of total urinary maternal arsenic levels (sum of iAs and urinary arsenic metabolites) to estimate exposure in some studies makes interpreting the exact contribution of iAs difficult when arsenic speciation information is not available during exposure assessment. In humans, inorganic arsenic and methylated metabolites (in urine range from 10%–30% inorganic arsenic, 10%–20% monomethylarsonic acid (MMA) and 60%–80% dimethylarsinic acid (DMA)) are considerably more toxic than organic forms of arsenic (Vahter and Concha, 2001). Organic arsenic is found in fish and shellfish, primarily in the forms of arsenobetaine, arsenosugars, and arsenolipids. As urinary excretion is the main route of elimination for both inorganic and organic arsenic species, in populations with high consumption of seafood, total urinary arsenic could primarily reflect organic arsenical exposure. In this case, the biomarker would not reflect toxic inorganic species well (Martinez-Morata et al., 2023). In order to distinguish between inorganic and organic arsenicals when seafood intake is prevalent in a study population, arsenic speciation and adjustment for arsenobetaine is recommended. Otherwise, the use of total As a biomarker in a population with higher seafood consumption could result in exposure misclassification, which could produce bias to the null, compared with use in a population with lower seafood intake. In other words, in populations with higher seafood intake, total As biomarker measures may provide a less accurate estimate of inorganic As exposure and would likely result in an underestimation of the true effect. For this reason, lack of consideration of speciation (i.e., analytically, statistical analyses) was considered during study evaluation in the exposure characterization domain, especially in populations where seafood consumption could be considered high. However, lack of speciation was not on its own considered a critical deficiency that would preclude consideration of the study for hazard characterization (when applicable) or dose-response analysis. The extent to which arsenobetaine was considered in urine biomarker studies used in dose response is presented in Sections 4.3.1, 4.4, and 4.5, where applicable. There are additional considerations for the use of biomarkers to evaluate exposure during pregnancy (Ashley-Martin et al., 2022).

While hair and nail biomarkers may give an indication of past exposure due to their slow growth, there may also be potential concerns with external contamination (NRC, 1999), although this concern may be less of an issue for nail biomarker studies compared with hair (Karagas et al., 2001b).

With all methods to assess exposure, there may be nondifferential misclassification if a cohort study utilized only a baseline measure of exposure, but actual exposure is expected to change over time. For example, the half-life of arsenic in urine is approximately 4 days (NRC, 1999), while the half-life in blood is only a few hours (NRC, 1999; Cohen et al., 2006). However, with continuing exposure, as is the case for many populations evaluated in studies considered for this assessment, arsenic biomarkers can represent steady-state and can serve as markers of past exposure. Similarly, even though many studies in the database did not report the gestational age at which arsenic exposure occurred, it was assumed that exposure occurred throughout gestation given the stability of the populations under study.

#### Urinary Concentration Correction Methods

Spot urine samples used to assess arsenic exposure are typically corrected for urine dilution due to the variable hydration status of study participants. Urine-creatinine and urine-specific gravity are common approaches to correct for physiological variation in water content of urine samples (Hsieh et al., 2019). Comparatively, uncorrected approaches without using timed urine specimens are more prone to introducing exposure measurement bias and therefore hinder accurate exposure assessment.

Data indicate that urinary arsenic corrected by urinary creatinine can be more closely correlated with blood arsenic and water arsenic, compared with urinary arsenic corrected by specific gravity (Abuawad et al. (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=10476448)). Yet results from both correction approaches can be similar, compared with uncorrected measures. For example, Kuo et al. (2022) studied the association of arsenic exposure with all-cause, cardiovascular, and cancer mortality evaluated different urinary concentration correction methods, including urine-creatinine and specific gravity, as well as no correction. Similar statistical inferences between urine-creatinine and specific gravity corrections were observed for all-cause and cancer mortality in this adult population (Kuo et al., 2022).

All urinary correction methods have limitations, and it is not possible to pick a clear “best” approach for all scenarios. Urine-creatinine levels can be influenced by factors including age, sex, muscle mass, body mass index, and comorbidities such as diabetes (Barr et al., 2005). Similarly, specific-gravity adjustment has limitations in individuals with kidney damage, metabolic conditions (including diabetes), or cardiovascular disease (Maull et al., 2012; Kuo et al., 2022). This led Kuo et al. (2022) to conclude that, for cardiovascular mortality or metabolic outcomes, the use of specific gravity to correct for urine dilution could result in “… misclassification, overadjustment, or multicollinearity.” Ultimately, Kuo et al. (2022) concluded that “… urine-creatinine correction may be a better method to correct for urine dilution when evaluating the effect of arsenic exposure for cardiovascular or metabolic outcomes …” and this conclusion was consistent with the results of the Hsieh et al. (2019) review. Overall, when outcomes under study are also potentially impacted by factors related to urine-creatinine or specific gravity, judgment is required to select the most appropriate adjustment approach for a given outcome.

In this assessment, lack of urinary correction (either urinary creatinine or specific gravity) was considered during study evaluation in the exposure characterization domain. However, lack of urinary correction was not on its own considered a limitation that would preclude consideration of the study for hazard characterization (when applicable) or dose-response analysis. Yet, for the final dose-response analyses, all studies incorporated an approach to correct for urinary dilution. Creatinine adjustment was most common.

If two approaches were available for urinary correction, expert judgment was used to select the approach carried forward. However, as described below in Section 4, there were scenarios where the outcome-specific dose-response methods dictated the preference for a specific type of urinary correction adjustment approach. More specifically, the El-Masri-Kenyon PBPK model (El-Masri and Kenyon, 2008; El-Masri et al., 2018a, b) established an empirical relationship between drinking water exposure and creatinine-adjusted urinary total As concentrations (Section 4.1). As such, only studies that reported creatinine-adjusted urinary concentrations were suitable for dose conversion and inclusion in the Bayesian dose-response meta-analysis, which relied on EPA’s physiologically based pharmacokinetic model. Specific gravity could be used when creatinine adjustment was not available for outcomes that did not rely on the El-Masri-Kenyon PBPK model for dose conversion.

#### Impact of Other Factors

Study evaluations for the arsenic assessment incorporated outcome-specific considerations for confounding, as is standard for IRIS assessments. Potential core outcome-specific confounders considered for each of the outcomes are listed below.

- [underlined: Diseases of the Circulatory System]: smoking, sex, age, hypertension, cholesterol, obesity, BMI, measure of SES (e.g., education/income)
- [underlined: Diabetes]: smoking, sex, age, BMI/waist circumference, current use of hypertension medications, smoking, physical activity, measure of SES (e.g., education/income)
- [underlined: Fetal, newborn, & infant health]: maternal smoking/alcohol use, maternal age, race/ethnicity, measure of SES (e.g., education/income), infant sex, parity, gestational age at birth, maternal BMI
- [underlined: Neurodevelopment]: maternal smoking, sex, age, measure of SES (e.g., education/income), birth weight, maternal smoking

With regard to consideration of seafood intake, approaches varied: some studies adjusted for seafood consumption, such as through speciating urinary arsenic and excluding arsenobetaine. Others confirmed low seafood consumption in the study population or asked participants not to consume seafood prior to study inclusion. Other studies did not address potential confounding by organic arsenic by seafood intake. Lack of consideration of speciation (in design or analysis) was considered during study evaluation, especially in populations where seafood consumption could be considered high. However, lack of speciation was not on its own considered a limitation that would preclude consideration of the study for hazard characterization (when applicable) or dose-response analysis.

Several outcomes impacted by arsenic exposure may be interrelated through mediation or confounding. For example, hypertension and diabetes could potentially be on the causal pathway between arsenic exposure and IHD; alternatively, they could confound the association. Similarly, low birth weight could potentially be on the causal pathway between arsenic and neurodevelopment, or alternatively confound the association. If a study appropriately adjusts for a confounder, potential bias from that confounder would be removed in the calculated effect estimate. If a study adjusts for a variable on the causal pathway (i.e., a mediator), the calculated effect estimate would not include any effect from the mediating variable. A model that included potential mediators would not have been preferred for analysis. Yet, converging findings of the adverse impacts of arsenic using varying approaches to adjustment provide more confidence in the overall conclusions and indicate a logical coherence in the evidence base. However, not all studies collected or accounted for information on interrelated outcomes consistently in their analyses. As such, expert judgment was an important aspect of the study evaluation process to determine the impact of varying approaches on the overall risk of bias.

#### Overall Study Confidence Determination

Once all evaluation domains were evaluated, the identified strengths and limitations were collectively considered by the reviewers to reach a final study confidence classification. Study evaluations are holistic judgments based on all domains considered. A judgment of deficient (or the equivalent in the prior system for study confidence) in one domain does not necessarily mean that the entire study is low confidence or unsuitable for dose-response. The study evaluations are aimed at discerning limitations that could substantively change a result presented in the study or the interpretation of that result, also considering the expected direction of the bias. There are no defined weights for the domains, and study reviewers are responsible for applying expert judgment to make the determination of overall study confidence rating. Recognizing the role of expert judgment in the process, evaluations are conducted at the health outcome level by at least two reviewers with documentation of the supporting rationale for each rating. After independently reviewing a study, the two reviewers discussed differences and resolved any discrepancies between their ratings and rationales. Conflict resolution by an additional reviewer was done as needed. Thus, the reviewers reached a consensus judgment regarding each evaluation domain and overall (confidence) determination. The study evaluation results were carried forward to inform evidence synthesis analyses. Overall study confidence determinations are defined below:

- High confidence: No notable deficiencies or concerns were identified; the potential for bias is unlikely or minimal, and the study used sensitive methodology.
- Medium confidence: Possible deficiencies or concerns were noted, but the limitations are unlikely to be of a notable degree or to have a notable impact on the results.
- Low confidence: Deficiencies or concerns were noted, and the potential for bias or inadequate sensitivity could have a significant impact on the study results or their interpretation. Low confidence results were given less weight than high or medium confidence results during evidence synthesis and judgment.
- Uninformative: Serious flaw(s) were identified that make the study results unusable. Uninformative studies were not considered further, except to highlight possible research gaps.

Figure 1-2 Study evaluation overview of epidemiological studies

### 1.6.3 Data Extraction and Visualizations

The detailed data extraction approach is provided in the iAs Protocol (link provided in Appendix A), Section 3.11. Data extraction and content management was initially carried out using ICF’s DRAGON and Litstream (https://www.icf-litstream.com/) before subsequent migration to HAWC in 2021. Not all studies that meet the PECO criteria went through data extraction. Given the abundance of studies, medium or high confidence studies were prioritized over low or uninformative studies for extraction and presentation in the assessment. Studies evaluated as uninformative were not considered further and therefore did not undergo data extraction and were not cited in the assessment. Low confidence studies did undergo extraction but were not incorporated into evidence synthesis analysis or forest plots due to the availability of a large number of medium and high confidence studies. Literature tag-trees contain lists of all studies tagged as uninformative, low confidence, medium confidence, and high confidence for each outcome (see Figures 3-3, 3-22, 3-27, 3-39).

All findings from medium or high confidence studies were considered for extraction, regardless of the statistical significance of their findings. Only results from the model that considered the most outcome-specific confounders (see Section 1.6.2 for core confounders) were selected for extraction. This was often the most fully adjusted model, but not always. For example, a model that included potential mediators would not have been preferred for data extraction and display (see Section 1.6.2 “Impact of Other Factors”). For quality control, data extraction was performed by one member of the evaluation team and independently verified by at least one other member. Discrepancies in data extraction were resolved by discussion or consultation within the evaluation team. Results from all medium and high confidence studies are visualized in figures throughout Section 3.2.

To be included in a forest plot, study results had to meet the following criteria (study results that did not fit criteria were listed or further described in Section 3.2 narrative):

- Must include a ratio measure or difference measure.
- At least two estimates that were generally comparable were required in order to create a plot. A forest plot was not created if the plot would only display a single estimate. For example, there was a single effect estimate for the grouping: Diseases of the Circulatory System, Ischemic Heart Disease, Ecological study design, therefore Tsai et al. (1999) does not appear in a plot.

Studies were grouped in the following order for presentation in forest plots:

- Outcome (DCS, Diabetes, Fetal and Infant Health. Neurodevelopment)
- Sub-outcome (if relevant)
- Study design (DCS, diabetes, and developmental neurocognitive sections only, given the large number of studies to display)
- Effect estimate (Ratio or difference measures)
- Exposure assessment (Biomarker or drinking water)
- Estimate of exposure (Categorical or continuous)

In the forest plots, the country where each epidemiology study was conducted was presented to provide information on relative environmental exposure levels. For summary purposes, higher exposures were considered to be from countries such as Bangladesh, China, and Chile, while lower exposures include the United States, Mexico, and Denmark. The intent of the figures is to facilitate qualitative analyses of patterns of associations across studies. Figures include studies that vary across different dimensions, such as the use different types of effect estimates, different exposure assessment techniques as described in the column labeled “Exposure metric,” the use of different reference and exposure groups, different transformations of the exposure variable, and different increments of arsenic for associated regression coefficients. Thus, quantitative comparisons of the magnitude of the associations between studies is not appropriate. In addition, comparisons between plots may not be appropriate as both logarithmic and arithmetic scales are used. Targeted supplemental data pivots for scenarios with maximum arsenic exposures ≤100 μg/L in drinking water were developed based on the following criteria: for studies based on drinking water exposure, analyses were included if the categorical exposure category was ≤100 μg/L or if the maximum concentration in the study population was ≤100 μg/L for continuous exposure. For studies based on biomarker of exposure, analyses were included if the authors documented or referenced secondary information indicating that the maximum arsenic concentration in drinking water for the study population was ≤100 μg/L.

### 1.6.4 Evidence Synthesis of Epidemiological Evidence

EPA has recognized arsenic as a known human carcinogen since 1988 (U.S. EPA, 1993, 1995). Skin, bladder, and lung cancer and skin lesions are acknowledged as known hazard outcomes for inorganic arsenic (NRC, 2013; IARC, 2004b, 2012; Health Canada, 2006; ATSDR, 2007) and were considered in the updated problem formulation and protocol (link provided in Appendix A) to have a human evidence synthesis judgment of robust. This assessment develops new evidence synthesis conclusions for diseases of the circulatory system, fetal, newborn, and infant health outcomes, neurodevelopmental effects, and diabetes. Although skin cancer and skin lesions are acknowledged as known hazard outcomes they were not considered for dose-response analyses in this assessment based on an initial relative risk over background screening analyses [see Section 5.1 of the protocol, link provided in Appendix A and Hobbie et al. (Hobbie et al., 2020)]. In brief, skin cancer and skin lesions did not seem likely to drive cancer dose-response conclusions, i.e., skin cancer and skin lesions had margin of exposure values at relatively high exposures not generally encountered in the U.S. In addition, the vast majority of studies on these outcomes did not meet the screening criteria for inclusion for dose-response (see iAs Protocol, Section 5 (link provided in Appendix A)) and of those that did (one study for skin lesions, two studies for skin cancer [basal cell carcinoma or squamous cell carcinoma]), none were expected to be drivers of dose-response conclusions in the assessment.

Each synthesis is written to provide a summary discussion of the available evidence that addresses considerations that may suggest causation adapted from considerations for causality using a structured evaluation of an adapted set of considerations first introduced by Sir Bradford Hill (Hill, 1965) including consistency, exposure-response relationship, strength of the association, temporal relationship, coherence, and “natural experiments” in humans (U.S. EPA, 1994, 2005a) (see the iAs Protocol (link provided in Appendix A), Table 3-5). Importantly, the approach to the process of evidence synthesis explicitly considers and incorporates the conclusions from the individual study evaluations.

Evidence synthesis was based on epidemiology studies of high and medium confidence given the size of the iAs evidence base. Syntheses articulated the strengths and the weaknesses of the available evidence organized around the considerations described in the iAs Protocol (link provided in Appendix A), Table 3-5 as well as issues that stem from the evaluation of individual studies (e.g., concerns about bias or sensitivity). The analysis typically included examination of results stratified by any or all of the following: study confidence classification (or specific issues within confidence evaluation domains), population, exposures (e.g., level, patterns [intermittent or continuous], duration, intensity), sensitivity (e.g., low vs. high), and other factors that were identified in the refined evaluation plan (e.g., sex, life stage, or other demographics). Study sensitivity assesses whether factors in the study’s design and conduct may reduce its ability to observe an effect if present. The number of studies and the differences encompassed by the studies determined the extent to which specific types of factors can be examined to stratify study results.

The analyses of several considerations (see the iAs Protocol (link provided in Appendix A), Table 3-7) were used to develop a strength-of-evidence judgment. The terms associated with the different strength of evidence judgments for the epidemiological evidence on each of the assessed health outcomes are robust, moderate, slight, indeterminate, and compelling evidence of no effect. The final output is a summary judgment of the evidence base for each potential human health effect based on epidemiological evidence. The terms associated with these summary judgments are evidence demonstrates, evidence indicates (likely), evidence suggests, evidence inadequate, and strong evidence of no effect. These judgments were reached utilizing considerations based on the human evidence given the scope of the assessment [(U.S. EPA, 2022) Handbook Table 11-5]. Robust evidence from humans leads to the strongest evidence integration conclusion of evidence demonstrates (U.S. EPA, 2022). For evaluations of carcinogenicity consistent with EPA’s Cancer Guidelines (U.S. EPA, 2005a), one of EPA’s standardized cancer descriptors was used as a shorthand characterization of the evidence integration narrative, describing the overall potential for carcinogenicity. These are (1) carcinogenic to humans, (2) likely to be carcinogenic to humans, (3) suggestive evidence of carcinogenic potential, (4) inadequate information to assess carcinogenic potential, or (5) not likely to be carcinogenic to humans. Because bladder cancer and lung cancer are accepted hazards, the corresponding cancer descriptors for these health outcomes are carcinogenic to humans.

### 1.6.5 Dose-Response Analysis

The dose-response methods employed in this assessment are summarized in Appendix C and detailed in several publications (Mendez et al., 2020; Hobbie et al., 2020; Allen et al., 2020b; Allen et al., 2020a). The dose-response methods adhere to existing EPA guidelines and support documents, especially EPA’s Benchmark Dose Technical Guidance (U.S. EPA, 2012), EPA’s Review of the Reference Dose and Reference Concentration Processes (U.S. EPA, 2002b), Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005a), and Supplemental Guidance for Assessing Susceptibility from Early-Life Exposure to Carcinogens (U.S. EPA, 2005b), and evolving practices in the IRIS program in consideration of recommendations provided by the National Academies of Sciences, Engineering, and Medicine and the National Research Council (NRC, 2001, 2009, 2011, 2013, 2014; NASEM, 2019, 2021).

As recommended by the NRC (2013) and supported during the 2019 NASEM review of the protocol (NASEM, 2019), EPA focused its dose-response analysis on epidemiological data. Given the extensive epidemiological evidence base of iAs studies, a screening level of modeling was performed to help prioritize endpoints and studies for dose-response analysis (Hobbie et al., 2020). The primary objectives of the exposure-response screening were to help identify health outcomes that warrant and allow for multiple-study dose-response meta-analyses, select the most appropriate data sets for modeling, and provide screening-level relative risk estimates for a broad set of health outcomes potentially useful for cost-benefit considerations. The screening analysis involved deriving and comparing study/data set-specific unitless ratios of the exposure associated with a defined relative risk increase over the background exposure (RRB) (Hobbie et al., 2020).

On the basis of the screening analysis results, more complex Bayesian dose-response meta-analysis dose-response analyses (Allen et al., 2020b; Allen et al., 2020a) were performed using select epidemiological studies for bladder cancer, lung cancer, diseases of the circulatory system (DCS) and diabetes (see Section 5.1 of the Protocol).^7^ In brief, for study selection, a series of study design considerations were applied to medium or high confidence studies to identify studies for dose response analysis. To be included, a study needed to meet certain key study characteristics (e.g., represent an outcome selected for dose-response, present drinking water, urinary, or toenail levels of arsenic, be a case-control or cohort design, and consider smoking as a confounder), present quantitative information on exposure and outcomes (e.g., report findings as odds ratio (OR), relative risk (RR), or hazard ratio (HR), present quantitative, categorical estimates of exposure, report present the number of cases and control, or person-years), and have other characteristics suitable for inclusion (e.g., be conducted in area considered applicable to U.S. exposure levels, be an incidence study (where necessary), and not be duplicative of other study populations). A stopping approach was used where the considerations were applied in a sequence and a study did not advance further if an inclusion criterion was not met.

The specific sequence of applying inclusion criteria sometimes varied across outcomes in order to increase efficiency of the process. For example, for lung cancer and bladder cancer the outcomes were already narrowed during hazard identification whereas several noncancer outcomes (diabetes, neurodevelopment, cardiovascular) needed to be further specified for dose-response analysis. The studies cited in evidence synthesis for diabetes (Section 3.2.2) included type 2 diabetes, type 1 diabetes, gestational diabetes, metabolic syndrome, and insulin resistance. However, dose-response focused on type 2 diabetes so confirming type 2 diabetes as the outcome was an early consideration in the stopping sequence. For neurodevelopmental effects and fetal, newborn, and infant health outcomes, confirming that studies investigated cognitive effects or birthweight (respectively) was an early consideration in the stopping sequence for study selection. For diseases of the circulatory system, the focus for dose-response was ischemic heart disease so confirming a study investigated ischemic heart disease (or atherosclerosis) was added to end of study selection workflow for diseases of the circulatory system. The specific study selection sequence applied to each health outcome is presented when displaying the results of this screening process in Sections 4.3, 4.4, and 4.5.

Additionally, fetal, newborn, and infant health outcomes and developmental neurotoxicity (i.e., developmental neurocognitive effects) were identified as being particularly important to EPA Program Offices for cost-benefit analyses and were thus prioritized for inclusion in the assessment. While the datasets for fetal, newborn, and infant health outcomes and neurodevelopmental, neurocognitive effects were not amenable to the Bayesian dose-response meta-analysis approach, they contained dose-response data that could be evaluated by other methods.

The dose-response meta-analysis approach used in this assessment involves the application of a flexible, nonlinear, logistic-power model to derive U.S. population-specific mean extra risk estimates with confidence intervals that reflect the uncertainty in the logistic-power slope estimates. Linear (cancer endpoints only) approximations (for estimating CSFs) and polynomial equations are fit to these risk-at-a-dose values. The linear relationships between the upper-bound risk and dose presented in this assessment are analogous to cancer slope factor (CSF) estimates that EPA has historically provided for cancer risks. The CSF approximate the upper-bound lifetime extra cancer risk from chronic ingestion of a chemical per unit of mass consumed per unit body weight per day (expressed as [μg/kg-day]^−1^). To calculate the exact mean or upper-bound lifetime extra risk at any dose, the lifetable approach can be applied using the dose of interest. EPA has provided endpoint-specific lifetables as supplemental materials so that these calculations can be performed.

The approaches EPA used to identify and address susceptible populations and lifestages and to quantify uncertainty and variability are summarized in Section 5.2 of the Protocol (link provided in Appendix A). In part, this involved the use of flexible dose-response models, model averaging, and Bayesian dose-response meta-analysis and sensitivity analyses to determine the impact of priors and other modeling assumptions. Sections 4.2 through 4.6 provide details concerning the application of these approaches to individual health outcomes and relevant endpoints.

Most of the epidemiological evidence for the bladder cancer, lung cancer, diabetes and DCS health outcomes is from general population cohort and case-control studies that report the relationship between increasing iAs exposure groups and relative risks (RRs) above a reference group (RR = 1). The reference group exposure differs for each study included in the dose-response meta-analysis. In this assessment, EPA’s dose-response meta-analyses estimate a health outcome-specific average (logistic-power model) slope and power parameter for that relationship across studies, then uses it to predict mean and upper-bound lifetime extra risks above an estimate of the U.S. risk at a zero iAs dose. An estimate of the zero-dose risk is obtained by extrapolation, using the logistic slope estimates obtained from the dose-response meta-analysis and assuming that U.S. lifetime background risks are associated with EPA’s U.S. background dose estimate of 0.0365 μg iAs/kg-day,^8^ 0.02 μg iAs/kg-day from dietary food consumption (Xue et al., 2010) and 0.0165 μg iAs/kg-day from drinking water.^9^ Where possible, U.S. background risks are estimated using published lifetables. An important aspect of the lifetable applications is that the exposure scenario used posits a continuous, full lifetime exposure to a constant iAs dose (see Section 4.3.4 for details).

This assessment derives separate oral noncancer reference doses (RfDs) for several endpoints, including IHD (defined as incident or fatal cases), diabetes, fetal, newborn, and infant health outcomes, and developmental neurocognitive effects. A single overall RfD is selected to cover all health outcomes across all organs/systems. Although this overall RfD represents the focus of these dose-response assessments, the organ/system-specific values can be useful for subsequent cumulative risk assessments that consider the combined effect of multiple exposures acting on a common organ/system or mechanism.

3 For water concentrations, 1 μg/L = 1 ppb.

4 Toxline has recently been moved into PubMed as part of a broad National Library of Medicine reorganization. Toxline searches can now be conducted within PubMed.

5 In brief, to be included for dose response, a study needed to meet certain key study characteristics (e.g., represent an outcome selected for dose-response, present drinking water, urinary, or toenail levels of arsenic, be a case-control or cohort design, and consider smoking as a confounder), present quantitative information on exposure and outcomes, present quantitative, categorical estimates of exposure, report present the number of cases and control, or person-years), and have other characteristics suitable for inclusion (e.g., be conducted in area considered applicable to U.S. exposure levels, be an incidence study (where necessary), and not be duplicative of other study populations).

6 The OHAT method was used for this assessment because the current approach being used in IRIS had not been fully developed at the time these study evaluations were being conducted (2012 to 2017).

7 The decision to not include some endpoints in the more complex Bayesian meta-regression analysis should not be interpreted to mean EPA dismisses these endpoints as health effects of concern with iAs exposure. Rather, the Agency focuses on the selected six endpoints as these were prioritized to better represent the toxicological profile for iAs.

8 EPA’s iAs PBPK model indicates that this level of intake is consistent with the estimated 1-5 μg/L urinary background levels of total arsenic (summing inorganic, monomethyl, and dimethyl arsenic forms) that NRC (2013) considered to a reasonable for the U.S. population.

9 Using median U.S. dietary consumption (Xue et al., 2010) and median U.S. Country average inorganic arsenic drinking water concentration (1.5 μg/L) from USGS data, (Mendez et al., 2017) multiplied by the average water intake rate in the U.S. population of 0.011 L/kg-day (U.S. EPA (2019), Table 3-1, “All Ages”).