# REFERENCES

Ackerman, AH; Creed, PA; Parks, AN; Fricke, MW; Schwegel, CA; Creed, JT; Heitkemper, DT; Vela, NP. (2005). Comparison of a chemical and enzymatic extraction of arsenic from rice and an assessment of the arsenic absorption from contaminated water by cooked rice. Environ Sci Technol 39: 5241–5246. 10.1021/es048150n.16082952
Adair, BM; Moore, T; Conklin, SD; Creed, JT; Wolf, DC; Thomas, DJ. (2007). Tissue distribution and urinary excretion of dimethylated arsenic and its metabolites in dimethylarsinic acid- or arsenate-treated rats. Toxicol Appl Pharmacol 222: 235–242. 10.1016/j.taap.2007.04.012.17559899
Agency), U. (2004). Risk assessment guidance for Superfund. Vol. I. Human health evaluation manual (Part E, supplemental guidance for dermal risk assessment). (EPA/540/R/99/005). Washington, DC: Office of Superfund Remediation and Technology Innovation. Available online at http://www.epa.gov/oswer/riskassessment/ragse/pdf/part_e_final_revision_10-03-07.pdf.
Ahmed, A; Hassan, I; Mosa, IM; Elsanadidy, E; Sharafeldin, M; Rusling, JF; Ren, S. (2019). An Ultra-Shapeable, Smart Sensing Platform Based on a Multimodal Ferrofluid-Infused Surface. Adv Mater Deerfield 31: e1807201. 10.1002/adma.201807201.
Ahsan, H; Chen, Y; Kibriya, MG; Slavkovich, V; Parvez, F; Jasmine, F; Gamble, MV; Graziano, JH. (2007). Arsenic metabolism, genetic susceptibility, and risk of premalignant skin lesions in Bangladesh. Cancer Epidemiol Biomarkers Prev 16: 1270–1278. 10.1158/1055-9965.EPI-06-0676 17548696
Al-Forkan, M; Wali, FB; Khaleda, L; Alam, MJ; Chowdhury, RH; Datta, A; Rahman, MZ; Hosain, N; Maruf, MF; Chowdhury, MAQ; Hasan, NKM, M; Shawon, II; Raqib, R. (2021). Association of arsenic-induced cardiovascular disease susceptibility with genetic polymorphisms. Sci Rep 11: 6263. 10.1038/s41598-021-85780-8.33737636
Allen, B; Shao, K; Hobbie, K; Mendez, W, Jr; Lee, JS; Cote, I; Druwe, I; Gift, J; Davis, JA. (2020a). Systematic dose-response of environmental epidemiologic studies: Dose and response pre-analysis. Environ Int 142: 105810. 10.1016/j.envint.2020.105810.32563010
Allen, B; Shao, K; Hobbie, K; Mendez, W, Jr; Lee, JS; Cote, I; Druwe, I; Gift, JS; Davis, JA. (2020b). Bayesian hierarchical dose-response meta-analysis of epidemiological studies: Modeling and target population prediction methods. Environ Int 145: 106111. 10.1016/j.envint.2020.106111.32971419
Andrews, FV; Branscum, A; Hystad, P; Smit, E; Afroz, S; Golam, M; Sharif, O; Rahman, M; Quamruzzaman, Q; Christiani, DC; Kile, ML. (2022). A prospective study of arsenic and manganese exposures and maternal blood pressure during gestation. Environ Res 214: 113845. 10.1016/j.envres.2022.113845.35830911
Anundi, I; Högberg, J; Vahter, M. (1982). GSH release in bile as influenced by arsenite. FEBS Lett 145: 285–288. 10.1016/0014-5793(82)80184-1.7128826
Aposhian, HV. (1997). Enzymatic methylation of arsenic species and other new approaches to arsenic toxicity [Review]. Annu Rev Pharmacol Toxicol 37: 397–419. 10.1146/annurev.pharmtox.37.1.397.9131259
Aposhian, HV; Aposhian, MM. (2006). Arsenic toxicology: Five questions [Review]. Chem Res Toxicol 19: 1–15. 10.1021/tx050106d.16411650
Arab YarMohammadi, A; Arbabi Bidgoli, S; Ziarati, P. (2021). Increased urinary arsenic concentration in newly diagnosed type 2 diabetes mellitus: a gender-independent, smoking-dependent exposure biomarker in older adults in Tehran. Environ Sci Pollut Res Int 28: 27769–27777. 10.1007/s11356-020-10261-w.33517531
Argos, M; Parvez, F; Chen, Y; Hussain, AZM, I; Momotaj, H; Howe, GR; Graziano, JH; Ahsan, H. (2007). Socioeconomic status and risk for arsenic-related skin lesions in Bangladesh. Am J Public Health 97: 825–831. 10.2105/AJPH.2005.078816.17395836
Argos, M; Parvez, F; Rahman, M; Rakibuz-Zaman, M; Ahmed, A; Hore, SK; Islam, T; Chen, Y; Pierce, BL; Slavkovich, V; Olopade, C; Yunus, M; Baron, JA; Graziano, JH; Ahsan, H. (2014). Arsenic and lung disease mortality in Bangladeshi adults. Epidemiology 25: 536–543. 10.1097/EDE.0000000000000106.24802365
Aschengrau, A; Zierler, S; Cohen, A. (1989). Quality of community drinking water and the occurrence of spontaneous abortion. Arch Environ Health 44: 283–290. 10.1080/00039896.1989.9935895.2554824
ATSDR (Agency for Toxic Substances and Disease Registry). (2007). Toxicological profile for arsenic (update) [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. http://www.atsdr.cdc.gov/toxprofiles/tp.asp?id=22&tid=3.
ATSDR (Agency for Toxic Substances and Disease Registry). (2016). Addendum to the toxicological profile for arsenic [ATSDR Tox Profile]. Atlanta, GA: Agency for Toxic Substances and Disease Registry, Division of Toxicology and Human Health Sciences. https://www.atsdr.cdc.gov/toxprofiles/Arsenic_addendum.pdf.
Aurora Niño, S; Morales-Martínez, A; Chi-Ahumada, E; Carrizales, L; Salgado-Delgado, R; Pérez-Severiano, F; Díaz-Cintra, S; Jiménez-Capdeville, ME; Zarazúa, S. (2019). Arsenic exposure contributes to the bioenergetic damage in an Alzheimer’s disease model. ACS Chemical Neuroscience 10: 323–336. 10.1021/acschemneuro.8b00278.30141907
Baastrup, R; Sørensen, M; Balstrøm, T; Frederiksen, K; Larsen, CL; Tjønneland, A; Overvad, K; Raaschou-Nielsen, O. (2008). Arsenic in drinking-water and risk for cancer in Denmark. Environ Health Perspect 116: 231–237. 10.1289/ehp.10623.18288323
Bagnardi, V; Zambon, A; Quatto, P; Corrao, G. (2004). Flexible meta-regression functions for modeling aggregate dose-response data, with an application to alcohol and mortality. Am J Epidemiol 159: 1077–1086.15155292
Barchowsky, A; Dudek, EJ; Treadwell, MD; Wetterhahn, KE. (1996). Arsenic induces oxidant stress and NF-kappa B activation in cultured aortic endothelial cells. Free Radic Biol Med 21: 783–790. 10.1016/0891-5849(96)00174-8.8902524
Barchowsky, A; Klei, LR; Dudek, EJ; Swartz, HM; James, PE. (1999). Stimulation of reactive oxygen, but not reactive nitrogen species, in vascular endothelial cells exposed to low levels of arsenite. Free Radic Biol Med 27: 1405–1412. 10.1016/S0891-5849(99)00186-0.10641735
Baris, D; Waddell, R; Beane Freeman, LE; Schwenn, M; Colt, JS; Ayotte, JD; Ward, MH; Nuckols, J; Schned, A; Jackson, B; Clerkin, C; Rothman, N; Moore, LE; Taylor, A; Robinson, G; Hosain, GM; Armenti, KR; Mccoy, R; Samanic, C; Hoover, RN; Fraumeni, JF; Johnson, A; Karagas, MR; Silverman, DT. (2016). Elevated Bladder Cancer in Northern New England: The Role of Drinking Water and Arsenic. J Natl Cancer Inst 108: A3. 10.1093/jnci/djw099.
Barr, DB; Wilder, LC; Caudill, SP; Gonzalez, AJ; Needham, LL; Pirkle, JL. (2005). Urinary creatinine concentrations in the US population: Implications for urinary biologic monitoring measurements. Environ Health Perspect 113: 192–200. 10.1289/ehp.7337.15687057
Bates, MN. (2004). High Capacity SNP Genotyping in Arsenic Induced Disease. (CRISP/2004/ES011665-04). Bates, MN.
Bates, MN; Rey, OA; Biggs, ML; Hopenhayn, C; Moore, LE; Kalman, D; Steinmaus, C; Smith, AH. (2004). Case-control study of bladder cancer and exposure to arsenic in Argentina. Am J Epidemiol 159: 381–389. 10.1093/aje/kwh054.14769642
Bates, MN; Smith, AH; Cantor, KP. (1995). Case-control study of bladder cancer and arsenic in drinking water. 141: 523–530.
Begum, M; Horowitz, J; Hossain, MI. (2012). Low-dose risk assessment for arsenic: A meta-analysis approach. Asia Pac J Public Health 27: NP20–NP35. 10.1177/1010539512466568.23188879
Betancourt, M. (2018). A conceptual introduction to Hamiltonian Monte Carlo (pp. 1–60). Betancourt, M. https://arxiv.org/pdf/1701.02434.pdf.
Bloom, MS; Neamtiu, IA; Surdu, S; Pop, C; Anastasiu, D; Appleton, AA; Fitzgerald, EF; Gurzau, ES. (2016). Low level arsenic contaminated water consumption and birth outcomes in Romania-An exploratory study. Reprod Toxicol 59: 8–16. 10.1016/j.reprotox.2015.10.012.26518419
Borenstein, M; Hedges, LV; Higgins, JPT; Rothstein, HR. (2009). Introduction to meta-analysis. Chichester, UK: John Wiley & Sons. 10.1002/9780470743386.
Brainard, J; Burmaster, DE. (1992). Bivariate distributions for height and weight of men and women in the United States. Risk Anal 12: 267–275. 10.1111/j.1539-6924.1992.tb00674.x.1502374
Buchet, JP; Geubel, A; Pauwels, S; Mahieu, P; Lauwerys, R. (1984). The influence of liver disease on the methylation of arsenite in humans. Arch Toxicol 55: 151–154. 10.1007/BF00316119.6497648
Buchet, JP; Lauwerys, R. (1985). Study of inorganic arsenic methylation by rat liver in vitro: Relevance for the interpretation of observations in man. Arch Toxicol 57: 125–129. 10.1007/BF00343122.4026571
Buchet, JP; Lauwerys, R; Roels, H. (1981). Comparison of the urinary excretion of arsenic metabolites after a single oral dose of sodium arsenite, monomethylarsonate, or dimethylarsinate in man. Int Arch Occup Environ Health 48: 71–79. 10.1007/BF00405933.6894292
Bulka, CM; Persky, VW; Daviglus, ML; Durazo-Arvizu, RA; Argos, M. (2019). Multiple metal exposures and metabolic syndrome: A cross-sectional analysis of the National Health and Nutrition Examination Survey 2011-2014. Environ Res 168: 397–405. 10.1016/j.envres.2018.10.022.30388496
Bulka, CM; Scannell Bryan, M; Lombard, MA; Bartell, SM; Jones, DK; Bradley, PM; Vieira, VM; Silverman, DT; Focazio, M; Toccalino, PL; Daniel, J; Backer, LC; Ayotte, JD; Gribble, MO; Argos, M. (2022). Arsenic in private well water and birth outcomes in the United States. Environ Int 163: 107176. 10.1016/j.envint.2022.107176.35349912
Burmaster, DE; Crouch, EA. (1997). Lognormal distributions for body weight as a function of age for males and females in the United States, 1976-1980. Risk Anal 17: 499–505. 10.1111/j.1539-6924.1997.tb00890.x.9323875
Butler, EE; Karagas, MR; Demidenko, E; Bellinger, DC; Korrick, SA. (2023). In utero arsenic exposure and early childhood motor development in the New Hampshire Birth Cohort Study. Front Epidemiol 3: 1139337. 10.3389/fepid.2023.1139337.38455900
Calabrese, EJ; Agathokleous, E. (2021). Accumulator plants and hormesis [Review]. Environ Pollut 274: 116526. 10.1016/j.envpol.2021.116526.33545523
Castriota, F; Acevedo, J; Ferreccio, C; Smith, AH; Liaw, J; Smith, MT; Steinmaus, C. (2018). Obesity and increased susceptibility to arsenic-related type 2 diabetes in Northern Chile. Environ Res 167: 248–254. 10.1016/j.envres.2018.07.022.30059859
CFSAN (U.S. Food and Drug Administration, Center for Food Safety and Applied Nutrition). (2023). Action level for inorganic arsenic in apple juice: guidance for industry.
Chafe, R; Aslanov, R; Sarkar, A; Gregory, P; Comeau, A; Newhook, LA. (2018). Association of type 1 diabetes and concentrations of drinking water components in Newfoundland and Labrador, Canada. BMJ Open Diabetes Res Care 6: e000466. 10.1136/bmjdrc-2017-000466.
Chang, CH; Liu, CS; Liu, HJ; Huang, CP; Huang, CY; Hsu, HT; Liou, SH; Chung, CJ. (2016). Association between levels of urinary heavy metals and increased risk of urothelial carcinoma. Int J Urol 23: 233–239. 10.1111/iju.13024.26663353
Chapin, RE; Adams, J; Boekelheide, K; Gray, LE, Jr; Hayward, SW; Lees, PS; Mcintyre, BS; Portier, KM; Schnorr, TM; Selevan, SG; Vandenbergh, JG; Woskie, S. R. (2008). NTP-CERHR expert panel report on the reproductive and developmental toxicity of bisphenol A. Birth Defects Res B Dev Reprod Toxicol 83: 157–395. 10.1002/bdrb.20147.18613034
Charbonneau, SM; Hollins, JG; Tam, GKH; Bryce, F; Ridgeway, JM; Wiles, RF. (1980). Whole-body retention, excretion and metabolism of [74As] arsenic acid in the hamster. Toxicol Lett 5: 175–182. 10.1016/0378-4274(80)90056-9.7466843
Charbonneau, SM; Tam, GKH; Bryce, F; Zawidzka, Z; Sandi, E. (1979). Metabolism of orally administered inorganic arsenic in the dog. Toxicol Lett 3: 107–113. 10.1016/0378-4274(79)90094-8.
Chen, C, -J; Chiou, H, -Y; Chiang, M, -H; Lin, L, -J; Tai, T, -Y. (1996). Dose-response relationship between ischemic heart disease mortality and long-term arsenic exposure. Arterioscler Thromb Vasc Biol 16: 504–510. 10.1161/01.ATV.16.4.504.8624771
Chen, C, -L; Hsu, L, -I; Chiou, H, -Y; Hsueh, Y, -M; Chen, S, -Y; Wu, M, -M; Chen, C, -J; Group, ftBDS. (2004). Ingested arsenic, cigarette smoking, and lung cancer risk: A follow-up study in arseniasis-endemic areas in Taiwan. JAMA 292: 2984–2990. 10.1001/jama.292.24.2984.15613666
Chen, CL; Chiou, HY; Hsu, LI; Hsueh, YM; Wu, MM; Chen, CJ. (2010a). Ingested arsenic, characteristics of well water consumption and risk of different histological types of lung cancer in northeastern Taiwan. Environ Res 110: 455–462. 10.1016/j.envres.2009.08.010.19735913
Chen, CL; Chiou, HY; Hsu, LI; Hsueh, YM; Wu, MM; Wang, YH; Chen, CJ. (2010b). Arsenic in drinking water and risk of urinary tract cancer: A follow-up study from northeastern Taiwan. Cancer Epidemiol Biomarkers Prev 19: 101–110. 10.1158/1055-9965.EPI-09-0333.20056628
Chen, H; Zhang, HL; Wang, X; Wu, Y; Zhang, YQ; Chen, SL; Zhang, WX; Sun, XJ; Zheng, TZ; Xia, W; Xu, SQ; Li, YY. (2023). Prenatal arsenic exposure, arsenic metabolism and neurocognitive development of 2-year-old children in low-arsenic areas. Environ Int 174: 107918. 10.1016/j.envint.2023.107918.37043832
Chen, W; Davis, EM; Stoner, JA; Robledo, C; Goodman, J. R.; Garwe, T; Janitz, AE; Xu, C; Hwang, J; Peck, JD. (2021). Urinary total arsenic and arsenic methylation capacity in pregnancy and gestational diabetes mellitus: A case-control study. Chemosphere 271: 129828. 10.1016/j.chemosphere.2021.129828.33736216
Chen, Y; Graziano, JH; Parvez, F; Liu, M; Slavkovich, V; Kalra, T; Argos, M; Islam, T; Ahmed, A; Rakibuz-Zaman, M; Hasan, R; Sarwar, G; Levy, D; van Geen, A; Ahsan, H. (2011). Arsenic exposure from drinking water and mortality from cardiovascular disease in Bangladesh: Prospective cohort study. Br Med J 342: d2431. 10.1136/bmj.d2431.21546419
Chen, Y; Wu, F; Liu, M; Parvez, F; Slavkovich, V; Eunus, M; Ahmed, A; Segers, S; Argos, M; Islam, T; Rakibuz-Zaman, M; Hasan, R; Sarwar, G; Levy, D; Graziano, J; Ahsan, H. (2013). A prospective study of arsenic exposure, arsenic methylation capacity, and risk of cardiovascular disease in Bangladesh. Environ Health Perspect 121: 832–838. 10.1289/ehp.1205797.23665672
Cheng, J; Li, YY; He, Q; Luo, LR; Zhang, YT; Gao, YH; Feng, HQ; Zhao, LJ; Wei, W; Fu, SB; Sun, DJ. (2021). Essential hypertension in patients exposed to high-arsenic exposed areas in western China: Genetic susceptibility and urinary arsenic metabolism characteristics. J Trace Elem Med Biol 67: 126778. 10.1016/j.jtemb.2021.126778.34087579
Chiou, H, -Y; Chiou, S, -T; Hsu, Y, -H; Chou, Y, -L; Tseng, C, -H; Wei, M, -L; Chen, C, -J. (2001). Incidence of transitional cell carcinoma and arsenic in drinking water: A follow-up study of 8,102 residents in an arseniasis-endemic area in northeastern Taiwan. Am J Epidemiol 153: 411–418. 10.1093/aje/153.5.411.11226969
Chiou, H, -Y; Huang, W, -I; Su, C, -L; Chang, S, -F; Hsu, Y, -H; Chen, C, -J. (1997). Dose-response relationship between prevalence of cerebrovascular disease and ingested inorganic arsenic. Stroke 28: 1717–1723. 10.1161/01.STR.28.9.1717.9303014
Chiou, HY; Hsueh, YM; Liaw, KF; Horng, SF; Chiang, MH; Pu, YS; Lin, JSN; Huang, CH; Chen, CJ. (1995). Incidence of internal cancers and ingested inorganic arsenic: A seven-year follow-up study in Taiwan. Cancer Res 55: 1296–1300.7882325
Chu, HA; Crawford-Brown, DJ. (2006). Inorganic arsenic in drinking water and bladder cancer: A meta-analysis for dose-response assessment. Int J Environ Res Public Health 3: 316–322. 10.3390/ijerph2006030039.17159272
Clewell, H; Efremenko, A; Black, M; Thomas, R; Wilga, P; Arnold, L; Gentry, PR; Yager, J. (2011). Arsenic induced gene expression changes in primary human uroepithelial cells. Toxicol Lett 205: S43–S43. 10.1016/j.toxlet.2011.05.170.
Clewell, HJ; Thomas, RS; Gentry, PR; Crump, KS; Kenyon, EM; El-Masri, HA; Yager, JW. (2007). Research toward the development of a biologically based dose response assessment for inorganic arsenic carcinogenicity: A progress report. Toxicol Appl Pharmacol 222: 388–398. 10.1016/j.taap.2007.03.021.17499324
Clewell, HJ; Yager, JW; Greene, TB; Gentry, PR. (2018). Application of the adverse outcome pathway (AOP) approach to inform mode of action (MOA): A case study with inorganic arsenic. J Toxicol Environ Health A 81: 893–912. 10.1080/15287394.2018.1500326.30230972
Cohen, SM; Arnold, LL; Beck, BD; Lewis, AS; Eldan, M. (2013). Evaluation of the carcinogenicity of inorganic arsenic [Review]. Crit Rev Toxicol 43: 711–752. 10.3109/10408444.2013.827152.24040994
Cohen, SM; Arnold, LL; Eldan, M; Lewis, AS; Beck, BD. (2006). Methylated arsenicals: The implications of metabolism and carcinogenicity studies in rodents to human risk assessment [Review]. Crit Rev Toxicol 36: 99–133. 10.1080/10408440500534230.16736939
Cole, SR; Chu, H; Greenland, S. (2014). Maximum likelihood, profile likelihood, and penalized likelihood: a primer. Am J Epidemiol 179: 252–260. 10.1093/aje/kwt245.24173548
Concha, G; Nermell, B; Vahter, MV. (1998a). Metabolism of inorganic arsenic in children with chronic high arsenic exposure in northern Argentina. Environ Health Perspect 106: 355–359. 10.1289/ehp.98106355.9618352
Concha, G; Vogler, G; Lezcano, D; Nermell, B; Vahter, M. (1998b). Exposure to inorganic arsenic metabolites during early human development. Toxicol Sci 44: 185–190. 10.1093/toxsci/44.2.185.9742656
Concha, G; Vogler, G; Nermell, B; Vahter, M. (1998c). Low-level arsenic excretion in breast milk of native Andean women exposed to high levels of arsenic in the drinking water. Int Arch Occup Environ Health 71: 42–46. 10.1007/s004200050248.9523248
Coronado-González, JA; Del Razo, LM; García-Vargas, G; Sanmiguel-Salazar, F; Escobedo-de la Peña, J. (2007). Inorganic arsenic exposure and type 2 diabetes mellitus in Mexico. Environ Res 104: 383–389. 10.1016/j.envres.2007.03.004.17475235
Cross, JD; Dale, IM; Leslie, ACD; Smith, H. (1979). Industrial exposure to arsenic. Journal of Radioanal Chem 48: 197–208. 10.1007/BF02519786.
Crump, KS; Allen, B. (2011). Toward making epidemiologic data more useful for quantitative risk assessment. Open Epidemiol J 4: 30–44.
Cui, X; Kobayashi, Y; Hayakawa, T; Hirano, S. (2004). Arsenic speciation in bile and urine following oral and intravenous exposure to inorganic and organic arsenics in rats. Toxicol Sci 82: 478–487. 10.1093/toxsci/kfh265.15342953
D’Ippoliti, D; Santelli, E; De Sario, M; Scortichini, M; Davoli, M; Michelozzi, P. (2015). Arsenic in Drinking Water and Mortality for Cancer and Chronic Diseases in Central Italy, 1990-2010. PLoS ONE 10: e0138182. 10.1371/journal.pone.0138182.26383851
da Silva Nunes, FL; Vieira Cunha Lima, SC; Lyra, C; Marchioni, DM; Campos Pedrosa, LF; Barbosa Junior, F; Mauricio Sena-Evangelista, KC. (2022). The impact of essential and toxic elements on cardiometabolic risk factors in adults and older people. J Trace Elem Med Biol 72: 126991. 10.1016/j.jtemb.2022.126991.35597099
Dai, L; Lv, X; Chen, Z; Huang, Z; Li, B; Xie, Y; Duan, Y; Zhao, H; Wang, Y; Yu, Q; Li, S; Zhou, Y; Shen, X. (2020). Elevated whole blood arsenic level is associated with type 2 diabetes in coal-burning areas in Guizhou. Toxicol Appl Pharmacol 403: 115135. 10.1016/j.taap.2020.115135.32692994
Dai, YM; Lu, HY; Zhang, JM; Ding, JY; Wang, Z; Zhang, BY; Qi, XJ; Chang, XL; Wu, CH; Zhou, ZJ. (2023). Sex-specific associations of maternal and childhood urinary arsenic levels with emotional problems among 6-year-age children: Evidence from a longitudinal cohort study in China. Ecotoxicol Environ Saf 267: 115658. 10.1016/j.ecoenv.2023.115658.37925797
Das, D; Chatterjee, A; Mandal, BK; Samanta, G; Chakraborti, D; Chanda, B. (1995). Arsenic in ground water in six districts of West Bengal, India: The biggest arsenic calamity in the world: Part 2: Arsenic concentration in drinking water, hair, nails, urine, skin-scale and liver tissue (biopsy) of the affected people. Analyst 120: 917–924. 10.1039/AN9952000917.7741255
Dauphiné, DC; Smith, AH; Yuan, Y; Balmes, JR; Bates, MN; Steinmaus, C. (2013). Case-control study of arsenic in drinking water and lung cancer in California and Nevada. Int J Environ Res Public Health 10: 3310–3324. 10.3390/ijerph10083310.23917816
Davydiuk, T; Tao, J; Lu, X; Le, XC. (2023). Effects of Dietary Intake of Arsenosugars and Other Organic Arsenic Species on Studies of Arsenic Methylation Efficiency in Humans [Review]. 1: 236–248. 10.1021/envhealth.3c00090.
De Kimpe, J; Cornelis, R; Mees, L; Vanholder, R. (1996). Basal metabolism of intraperitoneally injected carrier-free 74As-labeled arsenate in rabbits. Fundam Appl Toxicol 34: 240–248. 10.1006/faat.1996.0193.8954753
De la Ossa, C; Ramírez-Giraldo, A; Arroyo-Alvis, K; Marrugo-Negrete, J; Díez, S. (2023). Neuropsychological effects and cognitive deficits associated with exposure to mercury and arsenic in children and adolescents of the Mojana region, Colombia. Environ Res 216: 114467. 10.1016/j.envres.2022.114467.36265603
de Water, E; Curtin, P; Gennings, C; Chelonis, JJ; Paule, M; Bixby, M; Mcrae, N; Svensson, K; Schnaas, L; Pantic, I; Téllez-Rojo, MM; Wright, RO; Horton, MK. (2022). Prenatal metal mixture concentrations and reward motivation in children. Neurotoxicology 88: 124–133. 10.1016/j.neuro.2021.11.008.34793781
Del Razo, LM; Styblo, M; Cullen, WR; Thomas, DJ. (2001). Determination of trivalent methylated arsenicals in biological matrices. Toxicol Appl Pharmacol 174: 282–293. 10.1006/taap.2001.9226.11485389
Delnomdedieu, M; Basti, MM; Styblo, M; Otvos, JD; Thomas, DJ. (1994a). Complexation of arsenic species in rabbit erythrocytes. Chem Res Toxicol 7: 621–627. 10.1021/tx00041a006.7841340
Delnomdedieu, M; Bastic, MM; Otvosc, JD; Thomas, DJ. (1994b). Reduction and binding of arsenate and dimethylarsinate by glutathione: A magnetic resonance study. Chem Biol Interact 90: 139–155. 10.1016/0009-2797(94)90099-X.8156604
Delnomdedieu, M; Styblo, M; Thomas, DJ. (1995). Time dependence of accumulation and binding of inorganic and organic arsenic species in rabbit erythrocytes. Chem Biol Interact 98: 69–83. 10.1016/0009-2797(95)03636-Z.7586052
Desai, G; Niu, Z; Luo, W; Frndak, S; Shaver, AL; Kordas, K. (2021). Low-level exposure to lead, mercury, arsenic, and cadmium, and blood pressure among 8-17-year-old participants of the 2009-2016 National Health and Nutrition Examination Survey. Environ Res 197: 111086. 10.1016/j.envres.2021.111086.33781774
Dheer, R; Patterson, J; Dudash, M; Stachler, EN; Bibby, KJ; Stolz, DB; Shiva, S; Wang, Z; Hazen, SL; Barchowsky, A; Stolz, JF. (2015). Arsenic induces structural and compositional colonic microbiome change and promotes host nitrogen and amino acid metabolism. Toxicol Appl Pharmacol 289: 397–408. 10.1016/j.taap.2015.10.020.26529668
Doherty, BT; Romano, ME; Gui, J; Punshon, T; Jackson, BP; Karagas, MR; Korrick, SA. (2020). Periconceptional and prenatal exposure to metal mixtures in relation to behavioral development at 3 years of age. Environmental Epidemiology 4: e0106. 10.1097/EE9.0000000000000106.33154986
Dopp, E; Hartmann, LM; Florea, AM; von Recklinghausen, U; Pieper, R; Shokouhi, B; Rettenmeier, AW; Hirner, AV; Obe, G. (2004). Uptake of inorganic and organic derivatives of arsenic associated with induced cytotoxic and genotoxic effects in Chinese hamster ovary (CHO) cells. Toxicol Appl Pharmacol 201: 156–165. 10.1016/j.taap.2004.05.017.15541755
Douillet, C; Miller, M; Cable, P; Shi, Q; El-Masri, H; Matousek, T; Koller, B; Thomas, D; Styblo, M. (2023). Fate of arsenicals in mice carrying the human <i>AS3MT</i> gene exposed to environmentally relevant levels of arsenite in drinking water. Sci Rep 13: 3660. 10.1038/s41598-023-30723-8.36871058
Drobna, Z; Waters, SB; Devesa, V; Harmon, AW; Thomas, DJ; Styblo, M. (2005). Metabolism and toxicity of arsenic in human urothelial cells expressing rat arsenic (+3 oxidation state)-methyltransferase. Toxicol Appl Pharmacol 207: 147–159. 10.1016/j.taap.2004.12.007.16102566
Drobna, Z; Waters, SB; Walton, FS; Lecluyse, EL; Thomas, DJ; Styblo, M. (2004). Interindividual variation in the metabolism of arsenic in cultured primary human hepatocytes. Toxicol Appl Pharmacol 201: 166–177. 10.1016/j.taap.2004.05.004.15541756
Drobna, Z; Xing, W; Thomas, DJ; Styblo, M. (2006). shRNA silencing of AS3MT expression minimizes arsenic methylation capacity of HepG2 cells. Chem Res Toxicol 19: 894–898. 10.1021/tx060076u.16841956
Dzierlenga, M, .W.; Crawford, L, .; Longnecker, M, .P. (2020). Birth weight and perfluorooctane sulfonic acid: a random-effects meta-regression analysis. Environmental Epidemiology 4: e095. 10.1097/EE9.0000000000000095.33778349
Efremenko, A; Balbuena, P; Clewell, RA; Black, M; Pluta, L; Andersen, ME; Gentry, PR; Yager, JW; Clewell, HJ. (2021). Time-dependent genomic response in primary human uroepithelial cells exposed to arsenite for up to 60 days. Toxicology 461: 152893. 10.1016/j.tox.2021.152893.34425169
Efremenko, AY; Seagrave, J; Clewell, HJ; Van Landingham, C; Gentry, PR; Yager, JW. (2015). Evaluation of gene expression changes in human primary lung epithelial cells following 24-hr exposures to inorganic arsenic and its methylated metabolites and to arsenic trioxide. Environ Mol Mutagen 56: 477–490. 10.1002/em.21937.25873331
EFSA (European Food Safety Authority). (2009). Scientific opinion on arsenic in food. 7: 1351. 10.2903/j.efsa.2009.1351.
EFSA (European Food Safety Authority). (2014). Dietary exposure to inorganic arsenic in the European population. EFSA J 12: 3597.
Eick, SM; Ferreccio, C; Acevedo, J; Castriota, F; Cordero, JF; Roh, T; Smith, AH; Smith, MT; Steinmaus, C. (2019). Socioeconomic status and the association between arsenic exposure and type 2 diabetes. Environ Res 172: 578–585. 10.1016/j.envres.2019.03.013.30875511
El-Masri, HA; Hong, T; Henning, C; Mendez, W; Hudgens, EE; Thomas, DJ; Lee, JS. (2018a). Erratum: “Evaluation of a physiologically based pharmacokinetic (PBPK) model for inorganic arsenic exposure using data from two diverse human populations” [Erratum]. Environ Health Perspect 126: 99002. 10.1289/EHP4370.30392381
El-Masri, HA; Hong, T; Henning, C; Mendez, W; Hudgens, EE; Thomas, DJ; Lee, JS. (2018b). Evaluation of a Physiologically Based Pharmacokinetic (PBPK) Model for Inorganic Arsenic Exposure Using Data from Two Diverse Human Populations. Environ Health Perspect 126: 077004. 10.1289/EHP3096.30024383
El-Masri, HA; Kenyon, EM. (2008). Development of a human physiologically based pharmacokinetic (PBPK) model for inorganic arsenic and its mono- and di-methylated metabolites. J Pharmacokinet Pharmacodyn 35: 31–68. 10.1007/s10928-007-9075-z.17943421
Fan, C; Zhan, Z; Zhang, X; Lou, Q; Guo, N; Su, M; Gao, Y; Qin, M; Wu, L; Huang, W; Zhang, M; Yin, F; Wu, Y; Pi, J; Xu, Y; Yang, Y; Gao, Y. (2022). Research for type 2 diabetes mellitus in endemic arsenism areas in central China: role of low level of arsenic exposure and KEAP1 rs11545829 polymorphism. Arch Toxicol 96: 1673–1683. 10.1007/s00204-022-03279-1.35420349
Farzan, SF; Chen, Y, u; Rees, J. R.; Zens, MS; Karagas, MR. (2015a). Risk of death from cardiovascular disease associated with low-level arsenic exposure among long-term smokers in a US population-based study. Toxicol Appl Pharmacol 287: 93–97. 10.1016/j.taap.2015.05.013.26048586
Farzan, SF; Chen, Y; Wu, F; Jiang, J; Liu, M; Baker, E; Korrick, SA; Karagas, MR. (2015b). Blood pressure changes in relation to arsenic exposure in a U.S. pregnancy cohort. Environ Health Perspect 123: 999–1006. 10.1289/ehp.1408472.25793356
Farzan, SF; Eunus, HM; Haque, SE; Sarwar, G; Hasan, AR; Wu, F; Islam, T; Ahmed, A; Shahriar, M; Jasmine, F; Kibriya, MG; Parvez, F; Karagas, MR; Chen, Y; Ahsan, H. (2022). Arsenic exposure from drinking water and endothelial dysfunction in Bangladeshi adolescents. Environ Res 208: 112697. 10.1016/j.envres.2022.112697.35007543
FDA (U.S. Food and Drug Administration). (2005). Beverages: bottled water. Final rule. Fed Reg 70: 33694–33701.
FDA (U.S. Food and Drug Administration). (2020). Supporting document for action level for inorganic arsenic in rice cereals for infants. https://www.fda.gov/food/chemical-metals-natural-toxins-pesticides-guidance-documents-regulations/supporting-document-action-level-inorganic-arsenic-rice-cereals-infants.
FDA, US. (2016). Arsenic in Rice and Rice Products. Risk Assessment Report. Center for Food Safety and Applied Nutrition, Food and Drug Administration, U.S. Department of Health and Human Services. https://www.fda.gov/downloads/Food/FoodScienceResearch/RiskSafetyAssessment/UCM486543.pdf.
Ferreccio, C; González, C; Milosavjlevic, V; Marshall, G; Sancha, AM; Smith, AH. (2000). Lung cancer and arsenic concentrations in drinking water in Chile. Epidemiology 11: 673–679. 10.1097/00001648-200011000-00010.11055628
Freeman, GB; Schoof, RA; Ruby, MV; Davis, AO; Dill, JA; Liao, SC; Lapin, CA; Bergstrom, PD. (1995). Bioavailability of arsenic in soil and house dust impacted by smelter activities following oral administration in cynomolgus monkeys. Fundam Appl Toxicol 28: 215–222. 10.1093/toxsci/28.2.215.8835231
García-Esquinas, E; Pollán, M; Umans, JG; Francesconi, KA; Goessler, W; Guallar, E; Howard, B; Farley, J; Best, LG; Navas-Acien, A. (2013). Arsenic exposure and cancer mortality in a US-based prospective cohort: The strong heart study. Cancer Epidemiol Biomarkers Prev 22: 1944–1953. 10.1158/1055-9965.EPI-13-0234-T.23800676
Genaidy, AM; Lemasters, GK; Lockey, J; Succop, P; Deddens, J; Sobeih, T; Dunning, K. (2007). An epidemiological appraisal instrument - a tool for evaluation of epidemiological studies. Ergonomics 50: 920–960. 10.1080/00140130701237667.17457750
Gentry, PR; Clewell, HJ, III; Greene, TB; Franzen, AC; Yager, JW. (2014a). The impact of recent advances in research on arsenic cancer risk assessment. Regul Toxicol Pharmacol 69: 91–104. 10.1016/j.yrtph.2014.02.006.24534001
Gentry, PR; Covington, TR; Mann, S; Shipp, AM; Yager, JW; Clewell, HJ, III. (2004). Physiologically based pharmacokinetic modeling of arsenic in the mouse. J Toxicol Environ Health A 67: 43–71. 10.1080/15287390490253660.14668111
Gentry, PR; McDonald, TB; Sullivan, DE; Shipp, AM; Yager, JW; Clewell HJ, I. (2010). Analysis of genomic dose-response information on arsenic to inform key events in a mode of action for carcinogenicity [Review]. Environ Mol Mutagen 51: 1–14. 10.1002/em.20505.19551812
Gentry, PR; Yager, JW; Clewell, RA; Clewell, HJ, III. (2014b). Use of mode of action data to inform a dose-response assessment for bladder cancer following exposure to inorganic arsenic. Toxicol In Vitro 28: 1196–1205. 10.1016/j.tiv.2014.05.011.24937311
Geubel, AP; Mairlot, MC; Buchet, JP; Dive, C; Lauwerys, R. (1988). Abnormal methylation capacity in human liver cirrhosis. Int J Clin Pharmacol Res 8: 117–122.3378853
Ghaedrahmat, Z; Cheraghian, B; Jaafarzadeh, N; Takdastan, A; Shahbazian, HB; Ahmadi, M. (2021). Relationship between urinary heavy metals with metabolic syndrome and its components in population from Hoveyzeh cohort study: A case-control study in Iran. J Trace Elem Med Biol 66: 126757. 10.1016/j.jtemb.2021.126757.33839459
Gilbert-Diamond, D; Emond, JA; Baker, ER; Korrick, SA; Karagas, MR. (2016). Relation between in Utero Arsenic Exposure and Birth Outcomes in a Cohort of Mothers and Their Newborns from New Hampshire. Environ Health Perspect 124: 1299–1307. 10.1289/ehp.1510065.26955061
Gilbert-Diamond, D; Li, Z; Perry, AE; Spencer, SK; Gandolfi, AJ; Karagas, MR. (2013). A population-based case-control study of urinary arsenic species and squamous cell carcinoma in New Hampshire, USA. Environ Health Perspect 121: 1154–1160. 10.1289/ehp.1206178.23872349
Goodrich, JM; Ingle, ME; Domino, SE; Treadwell, MC; Dolinoy, DC; Burant, C; Meeker, JD; Padmanabhan, V. (2019). First trimester maternal exposures to endocrine disrupting chemicals and metals and fetal size in the Michigan Mother-Infant Pairs study. J Dev Orig Health Dis 10: 1–12. 10.1017/S204017441800106X.30919803
Grau-Perez, M; Caballero-Mateos, MJ; Domingo-Relloso, A; Navas-Acien, A; Gomez-Ariza, JL; Garcia-Barrera, T; Leon-Latre, M; Soriano-Gil, Z; Jarauta, E; Cenarro, A; Moreno-Franco, B; Laclaustra, M; Civeira, F; Casasnovas, JA; Guallar, E; Tellez-Plaza, M. (2022). Toxic Metals and Subclinical Atherosclerosis in Carotid, Femoral, and Coronary Vascular Territories: The Aragon Workers Health Study. Arterioscler Thromb Vasc Biol 42: 87–99. 10.1161/ATVBAHA.121.316358.34879710
Grau-Perez, M; Kuo, CC; Gribble, MO; Balakrishnan, P; Jones, S, pratlen, M.; Vaidya, D; Francesconi, KA; Goessler, W; Guallar, E; Silbergeld, EK; Umans, JG; Best, LG; Lee, ET; Howard, BV; Cole, SA; Navas-Acien, A. (2017). Association of low-moderate arsenic exposure and arsenic metabolism with incident diabetes and insulin resistance in the strong heart family study. Environ Health Perspect 125: 127004. 10.1289/EHP2566.29373862
Grau-Pérez, M; Kuo, CC; Spratlen, M; Thayer, KA; Mendez, MA; Hamman, RF; Dabelea, D; Adgate, JL; Knowler, WC; Bell, RA; Miller, FW; Liese, AD; Zhang, C; Douillet, C; Drobná, Z; Mayer-Davis, EJ; Styblo, M; Navas-Acien, A. (2017). The association of arsenic exposure and metabolism with type 1 and type 2 diabetes in youth: the search case-control study. Diabetes Care 40: 46–53. 10.2337/dc16-0810.27810988
Greenland, S; Longnecker, MP. (1992). Methods for trend estimation from summarized dose-response data, with applications to meta-analysis. Am J Epidemiol 135: 1301–1309.1626547
Greenland, S; Thomas, DC; Morgenstern, H. (1986). The rare-disease assumption revisited. A critique of “estimators of relative risk for case-control studies”. Am J Epidemiol 124: 869–883. 10.1093/oxfordjournals.aje.a114476.3776970
Gregg, EW; Zhuo, X; Cheng, YJ; Albright, AL; Narayan, KM; Thompson, TJ. (2014). Trends in lifetime risk and years of life lost due to diabetes in the USA, 1985–2011: A modelling study. Lancet Diabetes Endocrinol 2: 867–874. 10.1016/S2213-8587(14)70161-5.25128274
Gregus, Z; Németi, B. (2002). Purine nucleoside phosphorylase as a cytosolic arsenate reductase. Toxicol Sci 70: 13–19. 10.1093/toxsci/70.1.13.12388830
Gregus, Z; Németi, B. (2005). The glycolytic enzyme glyceraldehyde-3-phosphate dehydrogenase works as an arsenate reductase in human red blood cells and rat liver cytosol. Toxicol Sci 85: 859–869. 10.1093/toxsci/kfi158.15788719
Guo, JX; Hu, L; Yand, PZ; Tanabe, K; Miyatalre, M; Chen, Y. (2007). Chronic arsenic poisoning in drinking water in Inner Mongolia and its associated health effects. J Environ Sci Health A Tox Hazard Subst Environ Eng 42: 1853–1858. 10.1080/10934520701566918.17952786
Gustafson, P; Le, ND; Valleé, M. (2002). A Bayesian approach to case-control studies with errors in covariables. Biostatistics 3: 229–243. 10.1093/biostatistics/3.2.229.12933615
Hall, M; Gamble, M; Slavkovich, V; Liu, X; Levy, D; Cheng, Z; van Geen, A; Yunus, M; Rahman, M; Pilsner, JR; Graziano, J. (2007). Determinants of arsenic metabolism: Blood arsenic metabolites, plasma folate, cobalamin, and homocysteine concentrations in maternal-newborn pairs. Environ Health Perspect 115: 1503–1509. 10.1289/ehp.9906.17938743
Hamling, J; Lee, P; Weitkunat, R; Ambühl, M. (2008). Facilitating meta-analyses by deriving relative effect and precision estimates for alternative comparisons from a set of estimates presented by exposure level or disease category. Stat Med 27: 954–970. 10.1002/sim.3013.17676579
Han, YY; Weissfeld, JL; Davis, DL; Talbott, EO. (2009). Arsenic levels in ground water and cancer incidence in Idaho: An ecologic study. Int Arch Occup Environ Health 82: 843–849. 10.1007/s00420-008-0362-9.18941772
Hanlon, DP; Ferm, VH. (1977). Placental permeability of arsenate ion during early embryogenesis in the hamster. Experientia 33: 1221–1222. 10.1007/BF01922340.891884
Hansen, HR; Raab, A; Jaspars, M; Milne, BF; Feldmann, J. (2004). Sulfur-containing arsenical mistaken for dimethylarsinous acid [DMA(III)] and identified as a natural metabolite in urine: Major implications for studies on arsenic metabolism and toxicity. Chem Res Toxicol 17: 1086–1091. 10.1021/tx049978q.15310240
Harrington, JM; Middaugh, JP; Morse, DL; Housworth, J. (1978). A survey of a population exposed to high concentrations of arsenic in well water in Fairbanks, Alaska. Am J Epidemiol 108: 377–385.727207
Hayakawa, T; Kobayashi, Y; Cui, X; Hirano, S. (2005). A new metabolic pathway of arsenite: Arsenic-glutathione complexes are substrates for human arsenic methyltransferase Cyt19. Arch Toxicol 79: 183–191. 10.1007/s00204-004-0620-x.15526190
Hays, AM; Lantz, RC; Rodgers, LS; Sollome, JJ; Vaillancourt, RR; Andrew, AS; Hamilton, JW; Camenisch, TD. (2008). Arsenic-induced decreases in the vascular matrix. Toxicol Pathol 36: 805–817. 10.1177/0192623308323919.18812580
Health Canada. (2006). Guidelines for Canadian drinking water quality: Guideline technical document – Arsenic. Ottawa, Ontario: Water Quality and Health Bureau, Healthy Environments and Consumer Safety Branch, Health Canada. http://www.hc-sc.gc.ca/ewh-semt/alt_formats/hecs-sesc/pdf/pubs/water-eau/arsenic/arsenic-eng.pdf.
Healy, SM; Casarez, EA; Ayala-Fierro, F; Aposhian, H. (1998). Enzymatic methylation of arsenic compounds. V. Arsenite methyltransferase activity in tissues of mice. Toxicol Appl Pharmacol 148: 65–70. 10.1006/taap.1997.8306.9465265
Healy, SM; Wildfang, E; Zakharyan, RA; Aposhian, HV. (1999). Diversity of inorganic arsenite biotransformation [Review]. Biol Trace Elem Res 68: 249–266. 10.1007/BF02783907.10328340
Healy, SM; Zakharyan, RA; Aposhian, HV. (1997). Enzymatic methylation of arsenic compounds: IV. In vitro and in vivo deficiency of the methylation of arsenite and monomethylarsonic acid in the guinea pig. Mutat Res 386: 229–239. 10.1016/s1383-5742(97)00033-1.9219561
Heck, JE; Andrew, AS; Onega, T; Rigas, JR; Jackson, BP; Karagas, MR; Duell, EJ. (2009). Lung cancer in a U.S. population with low to moderate arsenic exposure. Environ Health Perspect 117: 1718–1723. 10.1289/ehp.0900566.20049123
Hendryx, M; Luo, J; Chojenta, C; Byles, JE. (2019). Exposure to heavy metals from point pollution sources and risk of incident type 2 diabetes among women: A prospective cohort analysis. Int J Environ Health Res 31: 1–12. 10.1080/09603123.2019.1668545.31204496
Herrera, A; Pineda, J; Antonio, MT. (2013). Toxic effects of perinatal arsenic exposure on the brain of developing rats and the beneficial role of natural antioxidants. Environ Toxicol Pharmacol 36: 73–79. 10.1016/j.etap.2013.03.018.23619517
Heydorn, K. (1970). Environmental variation of arsenic levels in human blood determined by neutron activation analysis. Clin Chim Acta 28: 349–357. 10.1016/0009-8981(70)90101-4.5447411
Higgins, JPT; Green, S. (2011). Cochrane handbook for systematic reviews of interventions. Version 5.1.0 (Updated March 2011). London, UK: The Cochrane Collaboration. http://handbook.cochrane.org/.
Higgins, JPT; Thomas, J; Chandler, J; Cumpston, M; Li, T; Page, MJ; Welch, VA. (2022). Cochrane handbook for systematic reviews of interventions version 6.3. Higgins, JPT; Thomas, J; Chandler, J; Cumpston, M; Li, T; Page, MJ; Welch, VA. http://www.training.cochrane.org/handbook.
Hill, AB. (1965). The environment and disease: Association or causation? Proc R Soc Med 58: 295–300. 10.1177/003591576505800503.14283879
Hobbie, K; Shao, K; Henning, C; Mendez, W, Jr; Lee, JS; Cote, I; Druwe, IL; Davis, JA; Gift, JS. (2020). Use of study-specific MOE-like estimates to prioritize health effects from chemical exposure for analysis in human health assessments. Environ Int 144: 105986. 10.1016/j.envint.2020.105986.32871380
Hood, RD; Vedel-Macrander, GC; Zaworotko, MJ; Tatum, FM; Meeks, RG. (1987). Distribution, metabolism, and fetal uptake of pentavalent arsenic in pregnant mice following oral or intraperitoneal administration. Teratology 35: 19–25. 10.1002/tera.1420350104.3563933
Hostýnek, JJ; Hinz, RS; Lorence, CR; Price, M; Guy, RH. (1993). Metals and the skin [Review]. Crit Rev Toxicol 23: 171–235. 10.3109/10408449309117116.8329115
Howe, CG; Margetaki, K; Vafeiadi, M; Roumeliotaki, T; Karachaliou, M; Kogevinas, M; McConnell, R; Eckel, SP; Conti, DV; Kippler, M; Farzan, SF; Chatzi, L. (2021). Prenatal metal mixtures and child blood pressure in the Rhea mother-child cohort in Greece. Environ Health 20: 1. 10.1186/s12940-020-00685-9.33407552
Hsieh, CY; Wang, SL; Fadrowski, JJ; Navas-Acien, A; Kuo, CC. (2019). Urinary concentration correction methods for arsenic, cadmium, and mercury: A systematic review of practice-based evidence. Curr Environ Health Rep 6: 188–199. 10.1007/s40572-019-00242-8.31372861
Huang, RN; Lee, TC. (1996). Cellular uptake of trivalent arsenite and pentavalent arsenate in KB cells cultured in phosphate-free medium. Toxicol Appl Pharmacol 136: 243–249. 10.1006/taap.1996.0031.8619232
Huang, Y, -K; Huang, Y, -L; Hsueh, Y, -M; Yang, M, -H; Wu, M, -M; Chen, S, -Y; Hsu, L, -I; Chen, C, -J. (2008a). Arsenic exposure, urinary arsenic speciation, and the incidence of urothelial carcinoma: A twelve-year follow-up study. Cancer Causes Control 19: 829–839. 10.1007/s10552-008-9146-5.18351295
Huang, Y, -K; Pu, Y, -S; Chung, C, -J; Shiue, H, -S; Yang, M, -H; Chen, C, -J; Hsueh, Y, -M. (2008b). Plasma folate level, urinary arsenic methylation profiles, and urothelial carcinoma susceptibility. Food Chem Toxicol 46: 929–938. 10.1016/j.fct.2007.10.017.18054417
Huedo-Medina, TB; Sánchez-Meca, J; Marín-Martínez, F; Botella, J. (2006). Assessing heterogeneity in meta-analysis: Q statistic or I2 index? Psychol Methods 11: 193–206. 10.1037/1082-989X.11.2.193.16784338
Hughes, MF. (2006). Biomarkers of exposure: A case study with inorganic arsenic [Review]. Environ Health Perspect 114: 1790–1796. 10.1289/ehp.9058.17107869
Hughes, MF; Del Razo, LM; Kenyon, EM. (2000). Dose-dependent effects on tissue distribution and metabolism of dimethylarsinic acid in the mouse after intravenous administration. Toxicology 143: 155–166. 10.1016/S0300-483X(99)00169-9.10755702
Hughes, MF; Devesa, V; Adair, BM; Styblo, M; Kenyon, EM; Thomas, DJ. (2005). Tissue dosimetry, metabolism and excretion of pentavalent and trivalent monomethylated arsenic in mice after oral administration. Toxicol Appl Pharmacol 208: 186–197. 10.1016/j.taap.2005.02.008.16183392
Hughes, MF; Kenyon, EM. (1998). Dose-dependent effects on the disposition of monomethylarsonic acid and dimethylarsinic acid in the mouse after intravenous administration. J Toxicol Environ Health A 53: 95–112.9444314
Hughes, MF; Kenyon, EM; Edwards, BC; Mitchell, CT; Del Razo, LM; Thomas, DJ. (2003). Accumulation and metabolism of arsenic in mice after repeated oral administration of arsenate. Toxicol Appl Pharmacol 191: 202–210. 10.1016/S0041-008X(03)00249-7.13678653
Hughes, MF; Kenyon, EM; Edwards, BC; Mitchell, CT; Thomas, DJ. (1999). Strain-dependent disposition of inorganic arsenic in the mouse. Toxicology 137: 95–108. 10.1016/S0300-483X(99)00068-2.10521146
IARC (International Agency for Research on Cancer). (2004a). IARC Monographs on the evaluation of carcinogenic risks to humans. Volume 83: Tobacco smoke and involuntary smoking. Lyon, France: World Health Organization, IARC. https://monographs.iarc.fr/wp-content/uploads/2018/06/mono83.pdf.
IARC (International Agency for Research on Cancer). (2004b). Some drinking-water disinfectants and contaminants, including arsenic [IARC Monograph] (pp. 1–477). Lyon, France. http://monographs.iarc.fr/ENG/Monographs/vol84/index.php.
IARC (International Agency for Research on Cancer). (2012). Arsenic, metals, fibres and dusts. IARC monographs on the evaluation of carcinogenic risks to humans, vol. 100C: A review of human carcinogens [IARC Monograph]. Lyon, France: World Health Organization. http://monographs.iarc.fr/ENG/Monographs/vol100C/mono100C.pdf.
Ilienko, A. (2013). Continuous counterparts of Poisson and binomial distributions and their properties. Annales Univ Sci Budapest, Sect Comp 39: 137–147. 10.48550/arXiv.1303.5990.
Jacobson-Kram, D; Montalbano, D. (1985). The reproductive effects assessment group’s report on the mutagenicity of inorganic arsenic. Environ Mutagen 7: 787–804. 10.1002/em.2860070515.3899634
James, KA; Byers, T; Hokanson, JE; Meliker, JR; Zerbe, GO; Marshall, JA. (2015). Association between Lifetime Exposure to Inorganic Arsenic in Drinking Water and Coronary Heart Disease in Colorado Residents. Environ Health Perspect 123: 128–134. 10.1289/ehp.1307839.25350952
James, KA; Marshall, JA; Hokanson, JE; Meliker, JR; Zerbe, GO; Byers, TE. (2013). A case-cohort study examining lifetime exposure to inorganic arsenic in drinking water and diabetes mellitus. Environ Res 123: 33–38. 10.1016/j.envres.2013.02.005.23507312
Jia, X; Zhang, L; Zhao, J; Ren, M; Li, Z; Wang, J; Wang, S; Liu, Y; An, H; Li, Y; Yan, L; Li, Z; Liu, X; Pan, B; Ye, R. (2021). Associations between endocrine-disrupting heavy metals in maternal hair and gestational diabetes mellitus: A nested case-control study in China. Environ Int 157: 106770. 10.1016/j.envint.2021.106770.34314978
Jiang, CB; Kao, CS; Chien, LC; Chen, YJ; Liao, KW. (2022). Associations among prenatal and postnatal arsenic, lead, and cadmium exposures and motor development in 3-year-old children: A longitudinal birth cohort study in Taiwan. Environ Sci Pollut Res Int 29: 43191–43200. 10.1007/s11356-021-18321-5.35091938
Jin, X; Tian, X; Liu, Z; Hu, H; Li, X; Deng, Y; Li, N; Zhu, J. (2016). Maternal exposure to arsenic and cadmium and the risk of congenital heart defects in offspring. Reprod Toxicol 59: 109–116. 10.1016/j.reprotox.2015.12.007.26743994
Jin, Y; Xi, S; Li, X; Lu, C; Li, G; Xu, Y; Qu, C; Niu, Y; Sun, G. (2006). Arsenic speciation transported through the placenta from mother mice to their newborn pups. Environ Res 101: 349–355. 10.1016/j.envres.2005.11.006.16458287
Juhasz, AL; Smith, E; Weber, J; Rees, M; Rofe, A; Kuchel, T; Sansom, L; Naidu, R. (2006). In vivo assessment of arsenic bioavailability in rice and its significance for human health risk assessment. Environ Health Perspect 114: 1826–1831. 10.1289/ehp.9322.17185270
Juhasz, AL; Smith, E; Weber, J; Rees, M; Rofe, A; Kuchel, T; Sansom, L; Naidu, R. (2007). Comparison of in vivo and in vitro methodologies for the assessment of arsenic bioavailability in contaminated soils. Chemosphere 69: 961–966. 10.1016/j.chemosphere.2007.05.018.17585998
Kagey, BT; Bumgarner, JE; Creason, JP. (1977). Arsenic levels in maternal-fetal tissue sets. In DD Hemphill (Ed.), Trace substances in environmental health - XI (pp. 252–256). Columbia, MO: University of Missouri.
Kala, SV; Neely, MW; Kala, G; Prater, CI; Atwood, DW; Rice, JS; Lieberman, MW. (2000). The MRP2/cMOAT transporter and arsenic-glutathione complex formation are required for biliary excretion of arsenic. J Biol Chem 275: 33404–33408. 10.1074/jbc.M007030200.10938093
Karagas, MR; Tosteson, TD; Morris, JS; Demidenko, E; Mott, LA; Heaney, J; Schned, A. (2004). Incidence of transitional cell carcinoma of the bladder and arsenic exposure in New Hampshire. Cancer Causes Control 15: 465–472. 10.1023/B:CACO.0000036452.55199.a3.15286466
Karakis, I; Landau, D; Gat, R; Shemesh, N; Tirosh, O; Yitshak-Sade, M; Sarov, B; Novack, L. (2021). Maternal metal concentration during gestation and pediatric morbidity in children: an exploratory analysis. Environ Health Prev Med 26: 40. 10.1186/s12199-021-00963-z.33765932
Karakulak, UN; Bal, C; Gunduzoz, M; Buyuksekerci, M; Aladag, E; Sahiner, ML; Kaya, EB; Ozer, N; Yilmaz, OH; Erel, O. (2021). Assessment of Diastolic Function and Thiol-Disulphide Homeostasis in Arsenic-Exposed Workers. Zhonghua Minguo Xinzang Xuehui Zazhi 37: 86–96. 10.6515/ACS.202101_37(1).20200711A.
Kaufman, JA; Mattison, C; Fretts, AM; Umans, JG; Cole, SA; Voruganti, VS; Goessler, W; Best, LG; Zhang, Y; Tellez-Plaza, M; Navas-Acien, A; Gribble, MO. (2021). Arsenic, blood pressure, and hypertension in the Strong Heart Family Study. Environ Res 195: 110864. 10.1016/j.envres.2021.110864.33581093
Kenyon, EM; Del Razo, LM; Hughes, MF. (2005). Tissue distribution and urinary excretion of inorganic arsenic and Its methylated metabolites in mice following acute oral administration of arsenate. Toxicol Sci 85: 468–475. 10.1093/toxsci/kfi107.15703264
Kenyon, EM; Hughes, MF. (2001). A concise review of the toxicity and carcinogenicity of dimethylarsinic acid [Review]. Toxicology 160: 227–236. 10.1016/S0300-483X(00)00458-3.11246143
Kenyon, EM; Hughes, MF; Adair, BM; Highfill, JH; Crecelius, EA; Clewell, HJ; Yager, JW. (2008). Tissue distribution and urinary excretion of inorganic arsenic and its methylated metabolites in C57BL6 mice following subchronic exposure to arsenate in drinking water. Toxicol Appl Pharmacol 232: 448–455. 10.1016/j.taap.2008.07.018.18706920
Kenyon, EM; Hughes, MF; Levander, OA. (1997). Influence of dietary selenium on the disposition of arsenate in female B6C3F1 mouse. J Toxicol Environ Health A 51: 279–299. 10.1080/00984109708984027.
Kile, ML; Cardenas, A; Rodrigues, E; Mazumdar, M; Dobson, C; Golam, M; Quamruzzaman, Q; Rahman, M; Christiani, DC. (2016). Estimating Effects of Arsenic Exposure During Pregnancy on Perinatal Outcomes in a Bangladeshi Cohort. Epidemiology 27: 173–181. 10.1097/EDE.0000000000000416.26583609
Kim, T; Nefian, AV; Broxton, MJ. (2010). Photometric recovery of Apollo metric imagery with Lunar-Lambertian reflectance. Electronics Letters 46. 10.1049/el.2010.0032.
Kuo, CC; Balakrishnan, P; Gribble, MO; Best, LG; Goessler, W; Umans, JG; Navas-Acien, A. (2022). The association of arsenic exposure and arsenic metabolism with all-cause, cardiovascular and cancer mortality in the Strong Heart Study. Environ Int 159: 107029. 10.1016/j.envint.2021.107029.34890900
Kuo, CC; Howard, BV; Umans, JG; Gribble, MO; Best, LG; Francesconi, KA; Goessler, W; Lee, E; Guallar, E; Navas-Acien, A. (2015). Arsenic exposure, arsenic metabolism, and incident diabetes in the strong heart study. Diabetes Care 38: 620–627. 10.2337/dc14-1641.25583752
Kupsco, A; Kioumourtzoglou, MA; Just, AC; Amarasiriwardena, C; Estrada-Gutierrez, G; Cantoral, A; Sanders, AP; Braun, JM; Svensson, K; Brennan, KJM; Oken, E; Wright, RO; Baccarelli, AA; Téllez-Rojo, MM. (2019). Prenatal metal concentrations and childhood cardiometabolic risk using Bayesian kernel machine regression to assess mixture and interaction effects. Epidemiology 30: 263–273. 10.1097/EDE.0000000000000962.30720588
Kurttio, P; Pukkala, E; Kahelin, H; Auvinen, A; Pekkanen, J. (1999). Arsenic concentrations in well water and risk of bladder and kidney cancer in Finland. Environ Health Perspect 107: 705–710.10464069
Kwok, RK; Kaufmann, RB; Jakariya, M. (2006). Arsenic in drinking-water and reproductive health outcomes: A study of participants in the Bangladesh integrated nutrition programme. J Health Popul Nutr 24: 190–205.17195560
Laine, JE; Bailey, KA; Rubio-Andrade, M; Olshan, AF; Smeester, L; Drobná, Z; Herring, AH; Stýblo, M; García-Vargas, GG; Fry, RC. (2015). Maternal Arsenic Exposure, Arsenic Methylation Efficiency, and Birth Outcomes in the Biomarkers of Exposure to ARsenic (BEAR) Pregnancy Cohort in Mexico. Environ Health Perspect 123: 186–192. 10.1289/ehp.1307476.25325819
Lamm, SH; Engel, A; Kruse, MB; Feinleib, M; Byrd, DM; Lai, S; Wilson, R. (2004). Arsenic in drinking water and bladder cancer mortality in the United States: An analysis based on 133 U.S. counties and 30 years of observation. J Occup Environ Med 46: 298–306. 10.1097/01.jom.0000116801.67556.8f.15091293
Lanz, H, Jr; Wallace, PC; Hamilton, JG. (1950). The metabolism of arsenic in laboratory animals using As74 as a tracer. Univ Calif Publ Pharmacol 2: 263–282.24538272
Laparra, JM; Vélez, D; Barberá, R; Farré, R; Montoro, R. (2005a). Bioavailability of inorganic arsenic in cooked rice: Practical aspects for human health risk assessments. J Agric Food Chem 53: 8829–8833. 10.1021/jf051365b.16248591
Laparra, JM; Vélez, D; Barberá, R; Granero, L; Polache, A; Montoro, R; Farré, R. (2006). Cytotoxic effect of As(III) in Caco-2 cells and evaluation of its human intestinal permeability. Toxicol In Vitro 20: 658–663. 10.1016/j.tiv.2005.12.005.16472965
Laparra, JM; Velez, D; Barbera, R; Montoro, R; Farre, R. (2005b). An approach to As(III) and As(V) bioavailability studies with Caco-2 cells. Toxicol In Vitro 19: 1071–1078. 10.1016/j.tiv.2005.05.007.16023827
Lau, A; Whitman, SA; Jaramillo, MC; Zhang, DD. (2013). Arsenic-mediated activation of the Nrf2-Keap1 antioxidant pathway [Review]. J Biochem Mol Toxicol 27: 99–105. 10.1002/jbt.21463.23188707
Laue, HE; Moroishi, Y; Palys, TJ; Jackson, BP; Madan, JC; Karagas, MR. (2022). Contribution of gut bacteria to arsenic metabolism in the first year of life in a prospective birth cohort. Environ Res 214: 114099. 10.1016/j.envres.2022.114099.35998698
Le, XC; Lu, X; Ma, M; Cullen, WR; Aposhian, HV; Zheng, B. (2000a). Speciation of key arsenic metabolic intermediates in human urine. Anal Chem 72: 5172–5177. 10.1021/ac000527u.11080860
Le, XC; Ma, M; Lu, X; Cullen WR: Aposhian, HV; Zheng, B. (2000b). Determination of monomethylarsonous acid, a key arsenic methylation intermediate, in human urine. Environ Health Perspect 108: 1015–1018. 10.1289/ehp.001081015.
Lee, C, -H; Chen, J, -S; Sun, Y, -L; Liao, W, -T; Zheng, Y, -W; Chal, C, -Z; Chen, G, -S; Yu, H, -S. (2006). Defective β1-integrins expression in arsenical keratosis and arsenic-treated cultured human keratinocytes. J Cutan Pathol 33: 129–138. 10.1111/j.0303-6987.2006.00361.x.16420308
Lemaire, M; Lemarié, CA; Molina, MF; Schiffrin, EL; Lehoux, S; Mann, KK. (2011). Exposure to moderate arsenic concentrations increases atherosclerosis in ApoE-/- mouse model. Toxicol Sci 122: 211–221. 10.1093/toxsci/kfr097.21512104
Lerman, S; Clarkson, TW. (1983). The metabolism of arsenite and arsenate by the rat. Fundam Appl Toxicol 3: 309–314. 10.1016/S0272-0590(83)80145-6.6628893
Lerman, SA; Clarkson, TW; Gerson, RJ. (1983). Arsenic uptake and metabolism by liver cells is dependent on arsenic oxidation state. Chem Biol Interact 45: 401–406. 10.1016/0009-2797(83)90087-X.6883581
Leslie, EM; Haimeur, A; Waalkes, MP. (2004). Arsenic transport by the human multidrug resistance protein 1 (MRP1/ABCC1): Evidence that a tri-glutathione conjugate is required. J Biol Chem 279: 32700–32708. 10.1074/jbc.M404912200.15161912
Lewis, DR; Southwick, JW; Ouellet-Hellstrom, R; Rench, J; Calderon, RL. (1999). Drinking water arsenic in Utah: A cohort mortality study. Environ Health Perspect 107: 359–365. 10.2307/3434539.10210691
Li, CS; Loch-Caruso, R. (2007). Sodium arsenite inhibits migration of extravillous trophoblast cells in vitro. Reprod Toxicol 24: 296–302. 10.1016/j.reprotox.2007.06.002.17646079
Li, J; Waters, SB; Drobna, Z; Devesa, V; Styblo, M; Thomas, DJ. (2005). Arsenic (+3 oxidation state) methyltransferase and the inorganic arsenic methylation phenotype. Toxicol Appl Pharmacol 204: 164–169. 10.1016/j.taap.2004.12.002.15808521
Li, X; Wang, X; Park, SK. (2021). Associations between rice consumption, arsenic metabolism, and insulin resistance in adults without diabetes. Int J Hyg Environ Health 237: 113834. 10.1016/j.ijheh.2021.113834.34488179
Liao, KW; Chang, CH; Tsai, MS; Chien, LC; Chung, MY; Mao, IF; Tsai, YA; Chen, ML. (2018). Associations between urinary total arsenic levels, fetal development, and neonatal birth outcomes: A cohort study in Taiwan. Sci Total Environ 612: 1373–1379. 10.1016/j.scitotenv.2017.08.312.28898944
Liebscher, K; Smith, H. (1968). Essential and nonessential trace elements: A method of determining whether an element is essential or nonessential in human tissue. Arch Environ Occup Health 17: 881–890.
Lin, S; Shi, Q; Nix, FB; Styblo, M; Beck, MA; Herbin-Davis, KM; Hall, LL; Simeonsson, JB; Thomas, DJ. (2002). A novel S-adenosyl-L-methionine:Arsenic(III) methyltransferase from rat liver cytosol. J Biol Chem 277: 10792–10803. 10.1074/jbc.M110246200.
Lindberg, AL; Rahman, M; Persson, LA; Vahter, M. (2008). The risk of arsenic induced skin lesions in Bangladeshi men and women is affected by arsenic metabolism and the age at first exposure. Toxicol Appl Pharmacol 230: 9–16. 10.1016/j.taap.2008.02.001.18336856
Lindberg, AL; Sohel, N; Rahman, M; Persson, LA; Vahter, M. (2010). Impact of smoking and chewing tobacco on arsenic-induced skin lesions. Environ Health Perspect 118: 533–538. 10.1289/ehp.0900728.20064784
Lindgren, A; Danielsson, BRG; Dencker, L; Vahter, M. (1984). Embryotoxicity of arsenite and arsenate: Distribution in pregnant mice and monkeys and effects on embryonic cells in vitro. Acta Pharmacol Toxicol 54: 311–320. 10.1111/j.1600-0773.1984.tb01936.x.
Lindgren, A; Vahter, M; Dencker, L. (1982). Autoradiographic studies on the distribution of arsenic in mice and hamsters administered 74As-aresenite or -arsenate. Acta Pharmacol Toxicol 51: 253–265. 10.1111/j.1600-0773.1982.tb01023.x.
Liu, B; Pan, S; Dong, X; Qiao, H; Jiang, H; Krissansen, GW; Sun, X. (2006a). Opposing effects of arsenic trioxide on hepatocellular carcinomas in mice. Cancer Sci 97: 675–681. 10.1111/j.1349-7006.2006.00230.x.16827809
Liu, H; Lu, S; Zhang, B; Xia, W; Liu, W; Peng, Y; Zhang, H; Wu, K; Xu, S; Li, Y. (2018). Maternal arsenic exposure and birth outcomes: A birth cohort study in Wuhan, China. Environ Pollut 236: 817–823. 10.1016/j.envpol.2018.02.012.29462776
Liu, H; Pu, Y; Ai, S; Wang, X; He, S; Wang, K, e; Dang, Y. (2022a). The Relationship Between Preeclampsia and Arsenic Concentration in the Peripheral Blood [Review]. Biol Trace Elem Res 200: 3965–3974. 10.1007/s12011-021-02988-5.34993909
Liu, J; Zheng, B; Aposhian, HV; Zhou, Y; Chen, ML; Zhang, A; Waalkes, MP. (2002). Chronic arsenic poisoning from burning high-arsenic-containing coal in Guizhou, China [Review]. Environ Health Perspect 110: 119–122.
Liu, M; Li, M; Guo, W; Zhao, L; Yang, H; Yu, J; Liu, L; Fang, Q; Lai, X; Yang, L; Zhu, K; Dai, W; Mei, W; Zhang, X. (2022b). Co-exposure to priority-controlled metals mixture and blood pressure in Chinese children from two panel studies. Environ Pollut 306: 119388. 10.1016/j.envpol.2022.119388.35526645
Liu, X; Zhang, D; Wu, X; Tu, J; Gong, C; Li, Y; Cui, W; Chen, J; Lu, S. (2022c). Urinary metals as influencing factors of coronary heart disease among a population in Guangzhou, China. Ecotoxicol Environ Saf 241: 113746. 10.1016/j.ecoenv.2022.113746.35689886
Liu, Z; Styblo, M; Rosen, BP. (2006b). Methylarsonous acid transport by aquaglyceroporins. Environ Health Perspect 114: 527–531. 10.1289/ehp.8600.16581540
Lloyd-Jones, DM; Larson, MG; Beiser, A; Levy, D. (1999). Lifetime risk of developing coronary heart disease. Lancet 353: 89–92. 10.1016/S0140-6736(98)10279-9.10023892
Loffredo, CA; Aposhian, HV; Cebrian, ME; Yamauchi, H; Silbergeld, EK. (2003). Variability in human metabolism of arsenic. Environ Res 92: 85–91. 10.1016/S0013-9351(02)00081-6.12854687
Lowney, YW; Wester, RC; Schoof, RA; Cushing, CA; Edwards, M; Ruby, MV. (2007). Dermal absorption of arsenic from soils as measured in the rhesus monkey. Toxicol Sci 100: 381–392. 10.1093/toxsci/kfm175.17872898
Lozano, M; Broberg, K; Soler-Blasco, R; Riutort-Mayol, G; Ballester, F; González, L; Murcia, M; Grimalt, J; Gil, F; Olmedo, P; Braeuer, S; Casas, M; Guxens, M; Irizar, A; Lertxundi, N; Zubero, M; Marina, L; Llop, S. (2024). Prenatal Metals Exposure and pre-adolescents’ Emotional and Behavioral Problems. Exposure and Health 16: 679–692. 10.1007/s12403-023-00585-6.
Lu, WJ; Tamai, I; Nezu, JI; Lai, ML; Huang, JD. (2006). Organic anion transporting polypeptide-C mediates arsenic uptake in HEK293 cells. J Biomed Sci 13: 525–533. 10.1007/s11373-006-9071-0.16479312
Lucio, M; Barbir, R; Vučić Lovrenčić, M; Canecki Varžić, S; Ljubić, S; Smirčić Duvnjak, L; Šerić, V; Milić, M; Tariba Lovaković, B; Krivohlavek, A; Vinković Vrček, I; Michalke, B. (2020). Association between arsenic exposure and biomarkers of type 2 diabetes mellitus in a Croatian population: A comparative observational pilot study. Sci Total Environ 720: 137575. 10.1016/j.scitotenv.2020.137575.32143048
Lynch, HN; Zu, K; Kennedy, EM; Lam, T; Liu, X; Pizzurro, DM; Loftus, CT; Rhomberg, LR. (2017a). Corrigendum to &quot;Quantitative assessment of lung and bladder cancer risk and oral exposure to inorganic arsenic: Meta-regression analyses of epidemiological data&quot; Environmental International 106 :178-206 [Erratum]. Environ Int 109: 195–196. 10.1016/j.envint.2017.10.004.29078863
Lynch, HN; Zu, K; Kennedy, EM; Lam, T; Liu, X; Pizzurro, DM; Loftus, CT; Rhomberg, LR. (2017b). Quantitative assessment of lung and bladder cancer risk and oral exposure to inorganic arsenic: Meta-regression analyses of epidemiological data. Environ Int 106: 178–206. 10.1016/j.envint.2017.04.008.28625818
Mahalingaiah, S; Meeker, JD; Pearson, KR; Calafat, AM; Ye, X; Petrozza, J; Hauser, R. (2008). Temporal variability and predictors of urinary bisphenol A concentrations in men and women. Environ Health Perspect 116: 173–178. 10.1289/ehp.10605.18288314
Maiorino, RM; Aposhian, HV. (1985). Dimercaptan metal-binding agents influence the biotransformation of arsenite in the rabbit. Toxicol Appl Pharmacol 77: 240–250. 10.1016/0041-008X(85)90323-0.2983455
Makhani, K; Chiavatti, C; Plourde, D; Negro Silva, LF; Lemaire, M; Lemarié, CA; Lehoux, S; Mann, KK. (2018). Using the Apolipoprotein E Knock-Out Mouse Model to Define Atherosclerotic Plaque Changes Induced by Low Dose Arsenic. Toxicol Sci 166: 213–218. 10.1093/toxsci/kfy201.30376133
Mandal, BK; Ogra, Y; Anzai, K; Suzuki, KT. (2004). Speciation of arsenic in biological samples. Toxicol Appl Pharmacol 198: 307–318. 10.1016/j.taap.2003.10.030.15276410
Mann, S; Droz, PO; Vahter, M. (1996a). A physiologically based pharmacokinetic model for arsenic exposure: I. Development in hamsters and rabbits. Toxicol Appl Pharmacol 137: 8–22. 10.1006/taap.1996.0052.8607145
Mann, S; Droz, PO; Vahter, M. (1996b). A physiologically based pharmacokinetic model for arsenic exposure: II. Validation and application in humans. Toxicol Appl Pharmacol 140: 471–486. 10.1006/taap.1996.0244.8887465
Mantha, M; Yeary, E; Trent, J; Creed, PA; Kubachka, K; Hanley, T; Shockey, N; Heitkemper, D; Caruso, J; Xue, J; Rice, G; Wymer, L; Creed, JT. (2016). Estimating inorganic arsenic exposure from U.S. rice and total water intakes. Environ Health Perspect 125: 057005. 10.1289/EHP418.
Mappes, R. (1977). Experiments on excretion of arsenic in urine]. Int Arch Occup Environ Health 40: 267–272. 10.1007/bf00381415.598936
Marafante, E; Rade, J; Sabbioni, E; Bertolero, F; Foa, V. (1981). Intracellular interaction and metabolic fate of arsenite in the rabbit. Clin Toxicol 18: 1335–1341. 10.3109/00099308109035074.7341060
Marafante, E; Vahter, M. (1984). The effect of methyltransferase inhibition on the metabolism of [74As] arsenite in mice and rabbits. Chem Biol Interact 50: 49–57. 10.1016/0009-2797(84)90131-5.6733804
Marafante, E; Vahter, M. (1987). Solubility, retention, and metabolism of intratracheally or orally administered inorganic arsenic compounds in the hamster. Environ Res 42: 72–82. 10.1016/S0013-9351(87)80008-7.3803345
Marafante, E; Vahter, M; Envall, J. (1985). The role of the methylation in the detoxication of arsenate in the rabbit. Chem Biol Interact 56: 225–238. 10.1016/0009-2797(85)90008-0.4075449
Marafante, E; Vahter, M; Norin, H; Envall, J; Sandstrom, M; Chistakopoulos, A; Ryhage, R. (1987). Biotransformation of dimethylarsinic acid in mouse, hamster and man. J Appl Toxicol 7: 111–117. 10.1002/jat.2550070207.3624766
Marano, KM; Naufal, ZS; Kathman, SJ; Bodnar, JA; Borgerding, MF; Wilson, CL. (2012). Arsenic exposure and tobacco consumption: Biomarkers and risk assessment. Regul Toxicol Pharmacol 64: 225–232. 10.1016/j.yrtph.2012.07.007.22874882
Marchiset-Ferlay, N; Savanovitch, C; Sauvant-Rochat, MP. (2012). What is the best biomarker to assess arsenic exposure via drinking water? [Review]. Environ Int 39: 150–171. 10.1016/j.envint.2011.07.015.22208756
Marcus, WL; Rispin, AS. (1988). Threshold carcinogenicity using arsenic as an example. In CR Cothern; MA Mehlman; WL Marcus (Eds.), Risk assessment and risk management of industrial and environmental chemicals (pp. 133–158). Princeton, NJ: Princeton Scientific Publishing Company, Inc.
Marie, C; Léger, S; Guttmann, A; Rivière, O; Marchiset, N; Lémery, D; Vendittelli, F; Sauvant-Rochat, MP. (2018). Exposure to arsenic in tap water and gestational diabetes: A French semi-ecological study. Environ Res 161: 248–255. 10.1016/j.envres.2017.11.016.29169099
Maull, EA; Ahsan, H; Edwards, J; Longnecker, MP; Navas-Acien, A; Pi, J; Silbergeld, EK; Styblo, M; Tseng, CH; Thayer, KA; Loomis, D. (2012). Evaluation of the association between arsenic and diabetes: A National Toxicology Program workshop review [Review]. Environ Health Perspect 120: 1658–1670. 10.1289/ehp.1104579.22889723
McGeer, J; Henningsen, G; Lanno, R; Fisher, N; Sappington, K; Drexler, J. (2004). Issue paper on the bioavailability and bioaccumulation of metals. Washington, DC: U.S. Environmental Protection Agency. https://www.epa.gov/osa/issue-paper-bioavailability-and-bioaccumulation-metals.
Mealey, J, Jr; Brownell, GL; Sweet, WH. (1959). Radioarsenic in plasma, urine, normal tissues, and intracranial neoplasms. AMA Arch Neurol Psychiatry 81: 310–320.13626282
Medina-Estevez, F; Zumbado, M; Luzardo, OP; Rodriguez-Hernandez, A; Boada, LD; Fernandez-Fuertes, F; Elvira Santandreu-Jimenez, M; Alberto Henriquez-Hernandez, L. (2020). Association between heavy metals and rare earth elements with acute ischemic stroke: A case-control study conducted in the Canary Islands (Spain). Toxics 8: 66. 10.3390/toxics8030066.32887274
Meliker, J. R.; Slotnick, MJ; Avruskin, GA; Schottenfeld, D; Jacquez, GM; Wilson, ML; Goovaerts, P; Franzblau, A; Nriagu, JO. (2010). Lifetime exposure to arsenic in drinking water and bladder cancer: A population-based case-control study in Michigan, USA. Cancer Causes Control 21: 745–757. 10.1007/s10552-010-9503-z.20084543
Mendez, WM; Eftim, S; Cohen, J; Warren, I; Cowden, J; Lee, JS; Sams, R. (2017). Relationships between arsenic concentrations in drinking water and lung and bladder cancer incidence in U.S. counties. J Expo Sci Environ Epidemiol 27: 235–243. 10.1038/jes.2016.58.27901016
Meza, M; Gandolfi, AJ; Klimecki, WT. (2007). Developmental and genetic modulation of arsenic biotransformation: A gene by environment interaction? Toxicol Appl Pharmacol 222: 381–387. 10.1016/j.taap.2006.12.018.17306849
Michaud, DS; Wright, ME; Cantor, KP; Taylor, PR; Virtamo, J; Albanes, D. (2004). Arsenic concentrations in prediagnostic toenails and the risk of bladder cancer in a cohort study of male smokers. Am J Epidemiol 160: 853–859. 10.1093/aje/kwh295.15496537
Miller, TW; Kaur, S; Ivins-O’Keefe, K; Roberts, DD. (2013). Thrombospondin-1 is a CD47-dependent endogenous inhibitor of hydrogen sulfide signaling in T cell activation. Matrix Biol 32: 316–324. 10.1016/j.matbio.2013.02.009.23499828
Molin, L; Wester, PO. (1976). The estimated daily loss of trace elements from normal skin by desquamation. Scand J Clin Lab Invest 36: 679–682. 10.3109/00365517609054495.1019579
Monrad, M; Ersbøll, AK; Sørensen, M; Baastrup, R; Hansen, B; Gammelmark, A; Tjønneland, A; Overvad, K; Raaschou-Nielsen, O. (2017). Low-level arsenic in drinking water and risk of incident myocardial infarction: A cohort study. Environ Res 154: 318–324. 10.1016/j.envres.2017.01.028.28157645
Moon, K; Guallar, E; Navas-Acien, A. (2012). Arsenic exposure and cardiovascular disease: An updated systematic review. Curr Atheroscler Rep 14: 542–555. 10.1007/s11883-012-0280-x.22968315
Moon, KA; Guallar, E; Umans, JG; Devereux, RB; Best, LG; Francesconi, KA; Goessler, W; Pollak, J; Silbergeld, EK; Howard, BV; Navas-Acien, A. (2013). Association between exposure to low to moderate arsenic levels and incident cardiovascular disease: A prospective cohort study. Ann Intern Med 159: 649–659. 10.7326/0003-4819-159-10-201311190-00719.24061511
Moon, KA; Oberoi, S; Barchowsky, A; Chen, Y; Guallar, E; Nachman, KE; Rahman, M; Sohel, N; D’Ippoliti, D; Wade, TJ; James, KA; Farzan, SF; Karagas, MR; Ahsan, H; Navas-Acien, A. (2017). A dose-response meta-analysis of chronic arsenic exposure and incident cardiovascular disease [Review]. Int J Epidemiol 46: 1924–1939. 10.1093/ije/dyx202.29040626
Moore, LE; Smith, AH; Eng, C; DeVries, S; Kalman, D; Bhargava, V; Chew, K; Ferreccio, C; Rey, OA; Hopenhayn, C; Biggs, ML; Bates, MN; Waldman, FM. (2003). P53 alterations in bladder tumors from arsenic and tobacco exposed patients. Carcinogenesis 24: 1785–1791. 10.1093/carcin/bgg136.12919957
Moore, LE; Smith, AH; Hopenhayn-Rich, C; Biggs, ML; Kalman, DA; Smith, MT. (1997). Micronuclei in exfoliated bladder cells among individuals chronically exposed to arsenic in drinking water. Cancer Epidemiol Biomarkers Prev 6: 31–36.8993795
Moser, G; Goldsworthy, TL; Tice, RR. (2000). Sodium arsenite studies in p53+/-mice. Denver, CO: American Water Works Association.
Mostafa, MG; Cherry, N. (2015). Arsenic in Drinking Water, Transition Cell Cancer and Chronic Cystitis in Rural Bangladesh. Int J Environ Res Public Health 12: 13739–13749. 10.3390/ijerph121113739.26516891
Mostafa, MG; McDonald, JC; Cherry, NM. (2008). Lung cancer and exposure to arsenic in rural Bangladesh. Occup Environ Med 65: 765–768. 10.1136/oem.2007.037895.18417558
Mukherjee, B; Sinha, S; Ghosh, M. (2005). Bayesian analysis of case-control studies. In DK Dey; CR Rao (Eds.), Handbook of statistics: Bayesian thinking, modeling and computation (pp. 793–819). Amsterdam, Netherlands: Elsevier. 10.1016/S0169-7161(05)25027-7.
Muller, P; Roeder, K. (1997). A Bayesian semiparametric model for case-control studies with errors in variables. Biometrika 84: 523–537. 10.1093/biomet/84.3.523.
Myers, SL; Lobdell, DT; Liu, Z; Xia, Y; Ren, H; Li, Y; Kwok, RK; Mumford, JL; Mendola, P. (2010). Maternal drinking water arsenic exposure and perinatal outcomes in Inner Mongolia, China. J Epidemiol Community Health 64: 325–329. 10.1136/jech.2008.084392.19692727
Naranmandura, H; Suzuki, N; Iwata, K; Hirano, S; Suzuki, KT. (2007). Arsenic metabolism and thioarsenicals in hamsters and rats. Chem Res Toxicol 20: 616–624. 10.1021/tx700038x.17381137
Nasab, H; Rajabi, S; Eghbalian, M; Malakootian, M; Hashemi, M; Mahmoudi-Moghaddam, H. (2022). Association of As, Pb, Cr, and Zn urinary heavy metals levels with predictive indicators of cardiovascular disease and obesity in children and adolescents. Chemosphere 294: 133664. 10.1016/j.chemosphere.2022.133664.35066075
NASEM (National Academies of Sciences, Engineering, and Medicine). (2019). Review of EPA’s updated problem formulation and protocol for the inorganic arsenic IRIS assessment. Washington, DC: The National Academies Press. 10.17226/25558.
NASEM (National Academies of Sciences, Engineering, and Medicine). (2021). Review of U.S. EPA’s ORD staff handbook for developing IRIS assessments: 2020 version. Washington, DC: National Academies Press. 10.17226/26289.
Nemeti, B; Csanaky, I; Gregus, Z. (2003). Arsenate reduction in human erythrocytes and rats--testing the role of purine nucleoside phosphorylase. Toxicol Sci 74: 22–31. 10.1093/toxsci/kfg116.12730608
Németi, B; Gregus, Z. (2002). Reduction of arsenate to arsenite in hepatic cytosol. Toxicol Sci 70: 4–12. 10.1093/toxsci/70.1.4.12388829
Németi, B; Gregus, Z. (2004). Glutathione-dependent reduction of arsenate in human erythrocytes--a process independent of purine nucleoside phosphorylase. Toxicol Sci 82: 419–428. 10.1093/toxsci/kfh301.15470234
Németi, B; Gregus, Z. (2005). Reduction of arsenate to arsenite by human erythrocyte lysate and rat liver cytosol - characterization of a glutathione- and NAD-dependent arsenate reduction linked to glycolysis. Toxicol Sci 85: 847–858. 10.1093/toxsci/kfi157.15788720
Ng, JC; Seawright, AA; Qi, L; Garnett, CM; Chiswell, B; Moore, MR. (1999). Tumours in mice induced by exposure to sodium arsenate in drinking water. In Arsenic Exposure and Health Effects. San Diego, CA: Elsevier Science B. V. 10.1016/b978-008043648-7/50025-x.
Nigra, AE; Moon, KA; Jones, MR; Sanchez, TR; Navas-Acien, A. (2021). Urinary arsenic and heart disease mortality in NHANES 2003-2014. Environ Res 200: 111387. 10.1016/j.envres.2021.111387.34090890
NIOSH (National Institute for Occupational Safety and Health). (2018). NIOSH pocket guide to chemical hazards. In NIOSH Pocket Guide to Chemical Hazards. Cincinnati, OH. http://www.cdc.gov/niosh/npg/npgdcas.html.
Notario-Barandiaran, L; Díaz-Coto, S; Jimenez-Redondo, N; Guxens, M; Vrijheid, M; Andiarena, A; Irizar, A; Riaño-Galan, I; Fernández-Somoano, A; Llop, S; Lozano, M; Karagas, MR; Meharg, A; Carey, M; Meharg, C; Ralphs, K; McCreanor, C; Vioque, J; Martinez-Camblor, P; Signes-Pastor, AJ. (2023). Latent childhood exposure to mixtures of metals and neurodevelopmental outcomes in 4-5-year-old children living in Spain. Exposure and Health 16: 1053–1066. 10.1007/s12403-023-00610-8.
NRC (National Research Council). (1994). Science and judgment in risk assessment. Washington, DC: National Academies Press. 10.17226/2125.
NRC (National Research Council). (1999). Arsenic in drinking water. Washington, DC: National Academy Press. http://www.nap.edu/catalog/6444.html.
NRC (National Research Council). (2001). Arsenic in drinking water: 2001 update. Washington, DC: National Academy Press. http://www.nap.edu/openbook.php?record_id=10194&page=R1.
NRC (National Research Council). (2013). Critical aspects of EPA’s IRIS assessment of inorganic arsenic: Interim report. Washington, DC: The National Academies Press. https://www.nap.edu/catalog/18594/critical-aspects-of-epas-iris-assessment-of-inorganic-arsenic-interim.
NRC (National Research Council). (2014). Review of EPA’s Integrated Risk Information System (IRIS) process. Washington, DC: The National Academies Press. 10.17226/18764.
NTP (National Toxicology Program). (2013). Draft OHAT approach for systematic review and evidence integration for literature-based health assessments – February 2013. National Institute of Environmental Health Sciences, National Institutes of Health. http://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/draftohatapproach_february2013.pdf.
NTP (National Toxicology Program). (2016). 14th Report on carcinogens. Research Triangle Park, NC. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html.
Odanaka, Y; Matano, O; Goto, S. (1980). Biomethylation of inorganic arsenic by the rat and some laboratory animals. Bull Environ Contam Toxicol 24: 452–459. 10.1007/BF01608138.
OEHHA (California Office of Environmental Health Hazard Assessment). (2014). Inorganic arsenic reference exposure levels (pp. 75–138). Sacramento, CA: Office of Environmental Health Hazard Assessment; California EPA. http://oehha.ca.gov/media/downloads/crnr/appendixd1final.pdf.
Orsini, N; Li, R; Wolk, A; Khudyakov, P; Spiegelman, D. (2012). Meta-analysis for linear and nonlinear dose-response relations: examples, an evaluation of approximations, and software. Am J Epidemiol 175: 66–73. 10.1093/aje/kwr265.22135359
OSHA (Occupational Safety & Health Administration). (2005). Inorganic arsenic standard; Extension of the Office of Management and Budget’s (OMB) approval of information collection (Paperwork) requirements. Fed Reg 70: 42389–42390.
Osorio-Yáñez, C; Ayllon-Vergara, JC; Aguilar-Madrid, G; Arreola-Mendoza, L; Hernández-Castellanos, E; Barrera-Hernández, A; De Vizcaya-Ruiz, A; Del Razo, LM. (2013). Carotid intima-media thickness and plasma asymmetric dimethylarginine in Mexican children exposed to inorganic arsenic. Environ Health Perspect 121: 1090–1096. 10.1289/ehp.1205994.23757599
Pan, WC; Seow, WJ; Kile, ML; Hoffman, EB; Quamruzzaman, Q; Rahman, M; Mahiuddin, G; Mostofa, G; Lu, Q; Christiani, DC. (2013). Association of low to moderate levels of arsenic exposure with risk of type 2 diabetes in Bangladesh. Am J Epidemiol 178: 1563–1570. 10.1093/aje/kwt195.24049161
Parr, RM; DeMaeyer, EM; Iyengar, VG; Byrne, AR; Kirkbright, GF; Schöch, G; Niinistö, L; Pineda, O; Vis, HL; Hofvander, Y. (1991). Minor and trace elements in human milk from Guatemala, Hungary, Nigeria, Philippines, Sweden, and Zaire. Results from a WHO/IAEA joint project. Biol Trace Elem Res 29: 51–75. 10.1007/BF03032674.1711362
Parvez, F; Wasserman, GA; Factor-Litvak, P; Liu, X; Slavkovich, V; Siddique, AB; Sultana, R; Sultana, R; Islam, T; Levy, D; Mey, JL; van Geen, A; Khan, K; Kline, J; Ahsan, H; Graziano, JH. (2011). Arsenic exposure and motor function among children in Bangladesh. Environ Health Perspect 119: 1665–1670. 10.1289/ehp.1103548.21742576
Patti, MA; Kelsey, KT; Macfarlane, AJ; Papandonatos, GD; Arbuckle, T; Ashley-Martin, J; Fisher, M; Fraser, WD; Lanphear, BP; Muckle, G; Braun, JM. (2022). Maternal Folate Status and the Relation between Gestational Arsenic Exposure and Child Health Outcomes. Int J Environ Res Public Health 19. 10.3390/ijerph191811332.
Paul, SK; Islam, MS; Hasibuzzaman, MM; Hossain, F; Anjum, A; Saud, ZA; Haque, MM; Sultana, P; Haque, A; Andric, KB; Rahman, A; Karim, MR; Siddique, AE; Karim, Y; Rahman, M; Miyataka, H; Xin, L; Himeno, S; Hossain, K. (2019). Higher risk of hyperglycemia with greater susceptibility in females in chronic arsenic-exposed individuals in Bangladesh. Sci Total Environ 668: 1004–1012. 10.1016/j.scitotenv.2019.03.029.31018442
Petrick, JS; Ayala-Fierro, F; Cullen, WR; Carter, DE; Vasken Aposhian, H. (2000). Monomethylarsonous acid (MMA(III)) is more toxic than arsenite in Chang human hepatocytes. Toxicol Appl Pharmacol 163: 203–207. 10.1006/taap.1999.8872.10698679
Petrick, JS; Jagadish, B; Mash, EA; Aposhian, HV. (2001). Monomethylarsonous acid (MMA(III)) and arsenite: LD(50) in hamsters and in vitro inhibition of pyruvate dehydrogenase. Chem Res Toxicol 14: 651–656. 10.1021/tx000264z.11409934
Pichler, G; Grau-Perez, M; Tellez-Plaza, M; Umans, J; Best, L; Cole, S; Goessler, W; Francesconi, K; Newman, J; Redon, J; Devereux, R; Navas-Acien, A, na. (2019). Association of arsenic exposure with cardiac geometry and left ventricular function in young adults evidence from the Strong Heart Family Study. Circulation: Cardiovascular Imaging 12: e009018. 10.1161/CIRCIMAGING.119.009018.31060373
Pomroy, C; Charbonneau, SM; Mccullough, RS; Tam, GKH. (1980). Human retention studies with 74As. Toxicol Appl Pharmacol 53: 550–556. 10.1016/0041-008X(80)90368-3.7385250
Prentice, RL. (1976). A generalization of the probit and logit methods for dose response curves. Biometrics 32: 761–768.1009225
Radabaugh, TR; Aposhian, HV. (2000). Enzymatic reduction of arsenic compounds in mammalian systems: Reduction of arsenate to arsenite by human liver arsenate reductase. Chem Res Toxicol 13: 26–30. 10.1021/tx990115k.10649963
Radabaugh, TR; Sampayo-Reyes, A; Zakharyan, RA; Aposhian, HV. (2002). Arsenate reductase II. Purine nucleoside phosphorylase in the presence of dihydrolipoic acid is a route for reduction of arsenate to arsenite in mammalian systems. Chem Res Toxicol 15: 692–698. 10.1021/tx0101853.12018991
Rahman, A; Vahter, M; Ekström, E, -C; Rahman, M; Golam Mustafa, AHM; Wahed, MA; Yunus, M; Persson, L, -Å. (2007). Association of arsenic exposure during pregnancy with fetal loss and infant death: A cohort study in Bangladesh. Am J Epidemiol 165: 1389–1396. 10.1093/aje/kwm025.17351293
Rahman, A; Vahter, M; Smith, AH; Nermell, B; Yunus, M; El Arifeen, S; Persson, L, -Å; Ekström, E, -C. (2009). Arsenic exposure during pregnancy and size at birth: A prospective cohort study in Bangladesh. Am J Epidemiol 169: 304–312. 10.1093/aje/kwn332.19037006
Rahman, M; Sohel, N; Yunus, M; Chowdhury, ME; Hore, SK; Zaman, K; Bhuiya, A; Streatfield, PK. (2014). A prospective cohort study of stroke mortality and arsenic in drinking water in Bangladeshi adults. BMC Public Health 14: 174. 10.1186/1471-2458-14-174.24548416
Rahman, MS; Hall, LL; Hughes, MF. (1994). In vitro percutaneous absorption of sodium arsenate in B6C3F1 mice. Toxicol In Vitro 8: 441–448. 10.1016/0887-2333(94)90166-X.20692936
Raml, R; Goessler, W; Francesconi, KA. (2006). Improved chromatographic separation of thio-arsenic compounds by reverse-phase high performance liquid chromatography-inductively coupled plasma mass spectrometry. J Chromatogr A 1128: 164–170. 10.1016/j.chroma.2006.06.061.16854422
Raml, R; Rumpler, A; Goessler, W; Vahter, M; Li, L; Ochi, T; Francesconi, KA. (2007). Thio-dimethylarsinate is a common metabolite in urine samples from arsenic-exposed women in Bangladesh. Toxicol Appl Pharmacol 222: 374–380. 10.1016/j.taap.2006.12.014.17276472
Rangel-Moreno, K; Gamboa-Loira, B; López-Carrillo, L; Cebrián, ME. (2022). Prevalence of type 2 diabetes mellitus in relation to arsenic exposure and metabolism in Mexican women. Environ Res 210: 112948. 10.1016/j.envres.2022.112948.35189103
Rasmussen, RE; Menzel, DB. (1997). Variation in arsenic-induced sister chromatid exchange in human lymphocytes and lymphoblastoid cell lines. Mutat Res 386: 299–306. 10.1016/S1383-5742(97)00010-0.9219567
Rehman, K; Fatima, F; Akash, MSH. (2019). Biochemical investigation of association of arsenic exposure with risk factors of diabetes mellitus in Pakistani population and its validation in animal model. Environ Monit Assess 191: 511. 10.1007/s10661-019-7670-2.31346790
RIVM (National Institute for Public Health and the Environment (Netherlands)). (2001). Re-evaluation of human-toxicological maximum permissible risk levels. (RIVM report 711701025). Bilthoven, Netherlands: National Institute for Public Health and the Environment (RIVM). https://www.rivm.nl/bibliotheek/rapporten/711701025.pdf.
Rothman, K; Greenland, S; Lash, T. (2008). Modern epidemiology. In Modern Epidemiology (3 ed.). Philadelphia, PA: Lippincott, Williams & Wilkins.
Rothman, KJ; Greenland, S. (1998). Modern epidemiology. In Modern Epidemiology (2 ed.). Philadelphia, PA: Lippincott-Raven.
Saady, JJ; Blanke, RV; Poklis, A. (1989). Estimation of the body burden of arsenic in a child fatally poisoned by arsenite weedkiller. J Anal Toxicol 13: 310–312.2615344
SAB (Science Advisory Board). (2024). Review of EPA’s draft IRIS toxicological review of inorganic arsenic: Final Report. (EPA-SAB-25-004). Washington, D.C.: U.S. Environmental Protection Agency (U.S. EPA). https://sab.epa.gov/ords/sab/f?p=114:0:1475375490519:APPLICATION_PROCESS=REPORT_DOC:::REPORT_ID:1136.
Saba, S; Akash, MSH; Rehman, K; Saleem, U; Fiayyaz, F; Ahmad, T. (2020). Assessment of heavy metals by ICP-OES and their impact on insulin stimulating hormone and carbohydrate metabolizing enzymes. Clin Exp Pharmacol Physiol 47: 1682–1691. 10.1111/1440-1681.13353.32434266
Saint-Jacques, N; Parker, L; Brown, P; Dummer, TJB. (2014). Arsenic in drinking water and urinary tract cancers: A systematic review of 30 years of epidemiological evidence [Review]. Environ Health 13: 44. 10.1186/1476-069X-13-44.24889821
Sakurai, T; Kaise, T; Matsubara, C. (1998). Inorganic and methylated arsenic compounds induce cell death in murine macrophages via different mechanisms. Chem Res Toxicol 11: 273–283. 10.1021/tx9701384.9548797
Sampayo-Reyes, A; Zakharyan, RA; Healy, SM; Aposhian, HV. (2000). Monomethylarsonic acid reductase and monomethylarsonous acid in hamster tissue. Chem Res Toxicol 13: 1181–1186. 10.1021/tx000154s.11087441
Sams, R, II; Wolf, DC; Ramasamy, S; Ohanian, E; Chen, J; Lowit, A. (2007). Workshop overview: Arsenic research and risk assessment. Toxicol Appl Pharmacol 222: 245–251. 10.1016/j.taap.2007.01.007.17336359
Scannell Bryan, M; Sofer, T; Mossavar-Rahmani, Y; Thyagarajan, B; Zeng, D; Daviglus, ML; Argos, M. (2019). Mendelian randomization of inorganic arsenic metabolism as a risk factor for hypertension- and diabetes-related traits among adults in the Hispanic Community Health Study/Study of Latinos (HCHS/SOL) cohort. Int J Epidemiol 48: 876–886. 10.1093/ije/dyz046.30929011
Schoof, RA; Eickhoff, J; Yost, LJ; Crecelius, EA; Cragin, DW; Meacher, DM; Menzel, DB. (1999a). Dietary exposure to inorganic arsenic. In WR Chappel; CO Abernathy; RL Calderon (Eds.), Arsenic exposure and health effects III (pp. 81–88). Amsterdam, Netherlands: Elsevier Science. 10.1016/B978-008043648-7/50011-X.
Schoof, RA; Yost, LJ; Eickhoff, J; Crecelius, EA; Cragin, DW; Meacher, DM; Menzel, DB. (1999b). A market basket survey of inorganic arsenic in food. Food Chem Toxicol 37: 839–846. 10.1016/s0278-6915(99)00073-3.10506007
Schwarzenbach, RP; Egli, T; Hofstetter, TB; Von Gunten, U; Wehrli, B. (2010). Global Water Pollution and Human Health. Annu Rev Environ Resour 35: 109–136. 10.1146/annurev-environ-100809-125342.
Scott, A. (1958). The retention of arsenic in the late cutaneous complications of its administration. Br J Dermatol 70: 195–200.13560707
Scott, N; Hatlelid, KM; Mackenzie, NE; Carter, DE. (1993). Reactions of arsenic(III) and arsenic(V) species with glutathione. Chem Res Toxicol 6: 102–106. 10.1021/tx00031a016.8448339
Shamliyan, T; Kane, RL; Dickinson, S. (2010). A systematic review of tools used to assess the quality of observational studies that examine incidence or prevalence and risk factors for diseases [Review]. J Clin Epidemiol 63: 1061–1070. 10.1016/j.jclinepi.2010.04.014.20728045
Shao, K; Allen, BC; Wheeler, MW. (2017). Bayesian Hierarchical Structure for Quantifying Population Variability to Inform Probabilistic Health Risk Assessments. Risk Anal 37: 1865–1878. 10.1111/risa.12751.28032899
Shao, K; Zhou, Z; Xun, P; Cohen, SM. (2021). Bayesian benchmark dose analysis for inorganic arsenic in drinking water associated with bladder and lung cancer using epidemiological data. Toxicology 455: 152752. 10.1016/j.tox.2021.152752.33741492
Shiobara, Y; Ogra, Y; Suzuki, KT. (2001). Animal species difference in the uptake of dimethylarsinous acid (DMA(III)) by red blood cells. Chem Res Toxicol 14: 1446–1452. 10.1021/tx015537k.11599937
Signes-Pastor, AJ; Romano, ME; Jackson, B; Braun, JM; Yolton, K; Chen, A; Lanphear, B; Karagas, MR. (2022). Associations of maternal urinary arsenic concentrations during pregnancy with childhood cognitive abilities: The HOME study. Int J Hyg Environ Health 245: 114009. 10.1016/j.ijheh.2022.114009.35947921
Simeonova, PP; Hulderman, T; Harki, D; Luster, MI. (2003). Arsenic exposure accelerates atherogenesis in apolipoprotein E(-/-) mice. Environ Health Perspect 111: 1744–1748. 10.1289/ehp.6332.14594625
Skalny, AV; Kopylov, PY; Paoliello, MMB; Chang, JS; Aschner, M; Bobrovnitsky, IP; Chao, JC; Aaseth, J; Chebotarev, SN; Tinkov, AA. (2021). Hair Lead, Aluminum, and Other Toxic Metals in Normal-Weight and Obese Patients with Coronary Heart Disease. Int J Environ Res Public Health 18. 10.3390/ijerph18158195.
Smith, AE; Lincoln, RA; Paulu, C; Simones, TL; Caldwell, KL; Jones, RL; Backer, LC. (2016). Assessing arsenic exposure in households using bottled water or point-of-use treatment systems to mitigate well water contamination. Sci Total Environ 544: 701–710. 10.1016/j.scitotenv.2015.11.136.26674699
Smith, AH; Ercumen, A; Yuan, Y; Steinmaus, CM. (2009). Increased lung cancer risks are similar whether arsenic is ingested or inhaled. J Expo Sci Environ Epidemiol 19: 343–348. 10.1038/jes.2008.73.19190673
Sobel, MH; Sanchez, TR; Jones, MR; Kaufman, JD; Francesconi, KA; Blaha, MJ; Vaidya, D; Shimbo, D; Gossler, W; Gamble, MV; Genkinger, JM; Navas-Acien, A. (2020). Rice intake, arsenic exposure, and subclinical cardiovascular disease among US adults in MESA. J Am Heart Assoc 9: e015658. 10.1161/JAHA.119.015658.32067593
Söderlind, P. (2013). Lecture notes - Econometrics: Some statistics. Available online at http://www.home.datacomm.ch/paulsoderlind/Courses/OldCourses/EcmXSta.pdf
Sohel, N; Persson, LÅ; Rahman, M; Streatfield, PK; Yunus, M; Ekström, E, -C; Vahter, M. (2009). Arsenic in drinking water and adult mortality: A population-based cohort study in rural Bangladesh. Epidemiology 20: 824–830. 10.1097/EDE.0b013e3181bb56ec.19797964
Soler-Blasco, R; Llop, S; Riutort-Mayol, G; Lozano, M; Vallejo-Ortega, J; Murcia, M; Ballester, F; Irizar, A; Andiarena, A; Fernandez-Jimenez, N; Braeuer, S; Harari, F. (2023). Genetic Susceptibility to Neurotoxicity Related to Prenatal Inorganic Arsenic Exposure in Young Spanish Children. Environ Sci Technol 57: 15366–15378. 10.1021/acs.est.3c03336.37787746
Soler-Blasco, R; Murcia, M; Lozano, M; Sarzo, B; Esplugues, A; Riutort-Mayol, G; Vioque, J; Lertxundi, N; Santa Marina, L; Lertxundi, A; Irizar, A; Braeuer, S; Ballester, F; Llop, S. (2022). Prenatal arsenic exposure, arsenic methylation efficiency, and neuropsychological development among preschool children in a Spanish birth cohort. Environ Res 207: 112208. 10.1016/j.envres.2021.112208.34662579
Soucy, NV; Ihnat, MA; Kamat, CD; Hess, L; Post, MJ; Klei, LR; Clark, C; Barchowsky, A. (2003). Arsenic stimulates angiogenesis and tumorigenesis in vivo. Toxicol Sci 76: 271–279. 10.1093/toxsci/kfg231.12970581
Soucy, NV; Mayka, D; Klei, LR; Nemec, AA; Bauer, JA; Barchowsky, A. (2005). Neovascularization and angiogenic gene expression following chronic arsenic exposure in mice. Cardiovasc Toxicol 5: 29–41. 10.1385/ct:5:1:029.15738583
Srivastava, S; Vladykovskaya, EN; Haberzettl, P; Sithu, SD; D’Souza, SE; States, JC. (2009). Arsenic exacerbates atherosclerotic lesion formation and inflammation in ApoE-/- mice. Toxicol Appl Pharmacol 241: 90–100. 10.1016/j.taap.2009.08.004.19682479
Stan Development Team. (2017). Stan modeling language user’s guide and reference manual. Available online at http://mc-stan.org/users/documentation/
Stein, CR; Wu, H; Bellinger, DC; Smith, DR; Wolff, MS; Savitz, DA. (2022). Exposure to metal mixtures and neuropsychological functioning in middle childhood. Neurotoxicology 93: 84–91. 10.1016/j.neuro.2022.09.003.36122627
Steinmaus, C; Yuan, Y; Bates, MN; Smith, AH. (2003). Case-control study of bladder cancer and drinking water arsenic in the western United States. Am J Epidemiol 158: 1193–1201. 10.1093/aje/kwg281.14652304
Steinmaus, CM. (2003). Mentored Training in Research on Arsenic. (CRISP/2003/ES011133-03). Steinmaus, CM.
Steinmaus, CM; Ferreccio, C; Romo, JA; Yuan, Y; Cortes, S; Marshall, G; Moore, LE; Balmes, JR; Liaw, J; Golden, T; Smith, AH. (2013). Drinking water arsenic in northern Chile: High cancer risks 40 years after exposure cessation. Cancer Epidemiol Biomarkers Prev 22: 623–630. 10.1158/1055-9965.EPI-12-1190.23355602
Stevens, JT; Hall, LL; Farmer, JD; Dipasquale, LC; Chernoff, N; Durham, WF. (1977). Disposition of 14C and/or 74As-cacodylic acid in rats after intravenous, intratracheal, or peroral administration. Environ Health Perspect 19: 151–157.908294
Straub, AC; Clark, KA; Ross, MA; Chandra, AG; Li, S; Gao, X; Pagano, PJ; Stolz, DB; Barchowsky, A. (2008). Arsenic-stimulated liver sinusoidal capillarization in mice requires NADPH oxidase-generated superoxide. J Clin Invest 118: 3980–3989. 10.1172/JCI35092.19033667
Styblo, M; Del Razo, LM; Vega, L; Germolec, DR; LeCluyse, EL; Hamilton, GA; Reed, W; Wang, C; Cullen, WR; Thomas, DJ. (2000). Comparative toxicity of trivalent and pentavalent inorganic and methylated arsenicals in rat and human cells. Arch Toxicol 74: 289–299. 10.1007/s002040000134.11005674
Styblo, M; Delnomdedieu, M; Thomas, DJ. (1996). Mono- and dimethylation of arsenic in rat liver cytosol in vitro. Chem Biol Interact 99: 147–164. 10.1016/0009-2797(95)03666-0.8620564
Styblo, M; Vega, L; Germolec, DR; Luster, MI; Del Razo, LM; Wang, C; Cullen, WR; Thomas, DJ. (1999). Metabolism and toxicity of arsenicals in cultured cells. In WR Chappell; CO Abernathy; RI Calderon (Eds.), Arsenic exposure and health effects (1 ed., pp. 311–323). Kidlington, Oxford, United Kingdom: Elsevier Science Ltd. 10.1016/b978-008043648-7/50035-2.
Styblo, M; Yamauchi, H; Thomas, DJ. (1995). Comparative in vitro methylation of trivalent and pentavalent arsenicals. Toxicol Appl Pharmacol 135: 172–178. 10.1006/taap.1995.1220.8545824
Suchy-Dicey, A; Noonan, C; Burduli, E; Mateen, FJ; Longstreth, WT, Jr; Buchwald, D; Navas-Acien, A. (2020). Urinary arsenic and cadmium associations with findings from cranial MRI in American Indians: Data from the Strong Heart Study. Environ Health Perspect 128: 127009. 10.1289/EHP6930.33332184
Tabacova, S; Baird, DD; Balabaeva, L; Lolova, D; Petrov, I. (1994). Placental arsenic and cadmium in relation to lipid peroxides and glutathione levels in maternal-infant pairs from a copper smelter area. Placenta 15: 873–881. 10.1016/S0143-4004(05)80188-2.7886027
Tam, GKH; Charbonneau, SM; Bryce, F; Pomroy, C; Sandi, E. (1979). Metabolism of inorganic arsenic (74As) in humans following oral ingestion. Toxicol Appl Pharmacol 50: 319–322. 10.1016/0041-008X(79)90157-1.505460
Tang, J; Zhu, Q; Xu, Y; Zhou, Y; Zhu, L; Jin, L; Wang, W; Gao, L; Chen, G; Zhao, H. (2022). Total arsenic, dimethylarsinic acid, lead, cadmium, total mercury, methylmercury and hypertension among Asian populations in the United States: NHANES 2011-2018. Ecotoxicol Environ Saf 241: 113776. 10.1016/j.ecoenv.2022.113776.35738098
TCEQ (Texas Commission on Environmental Quality). (2017). Inorganic arsenic oral slope factor. Developmental support document. Proposed, August 16 2017.
Thomas, DJ. (2007). Molecular processes in cellular arsenic metabolism [Review]. Toxicol Appl Pharmacol 222: 365–373. 10.1016/j.taap.2007.02.007.17397889
Thomas, DJ; Li, J; Waters, SB; Xing, W; Adair, BM; Drobna, Z; Devesa, V; Styblo, M. (2007). Arsenic (+3 oxidation state) methyltransferase and the methylation of arsenicals [Review]. Exp Biol Med 232: 3–13.
Thomas, DJ; Styblo, M; Lin, S. (2001). The cellular metabolism and systemic toxicity of arsenic [Review]. Toxicol Appl Pharmacol 176: 127–144. 10.1006/taap.2001.9258.11601889
Thomas, DJ; Waters, SB; Styblo, M. (2004). Elucidating the pathway for arsenic methylation. Toxicol Appl Pharmacol 198: 319–326. 10.1016/j.taap.2003.10.020.15276411
Tinkelman, NE; Spratlen, MJ; Domingo-Relloso, A; Tellez-Plaza, M; Grau-Perez, M; Francesconi, KA; Goessler, W; Howard, BV; MacCluer, J; North, KE; Umans, JG; Factor-Litvak, P; Cole, SA; Navas-Acien, A. (2020). Associations of maternal arsenic exposure with adult fasting glucose and insulin resistance in the Strong Heart Study and Strong Heart Family Study. Environ Int 137: 105531. 10.1016/j.envint.2020.105531.32059145
Torres-Arellano, JM; Osorio-Yáñez, C; Sánchez-Peña, LC; Ayllon-Vergara, JC; Arreola-Mendoza, L; Aguilar-Madrid, G; Del Razo, LM. (2020). Natriuretic peptides and echocardiographic parameters in Mexican children environmentally exposed to arsenic. Toxicol Appl Pharmacol 403: 115164. 10.1016/j.taap.2020.115164.32738329
Tseng, C, -H; Chong, C, -K; Tseng, C, -P; Hsueh, Y, -M; Chiou, H, -Y; Tseng, C, -C; Chen, C, -J. (2003). Long-term arsenic exposure and ischemic heart disease in arseniasis-hyperendemic villages in Taiwan. Toxicol Lett 137: 15–21. 10.1016/S0378-4274(02)00377-6.12505429
Tseng, C, -H; Huang, Y, -K; Huang, Y, -L; Chung, C, -J; Yang, M, -H; Chen, C, -J; Hsueh, Y, -M. (2005). Arsenic exposure, urinary arsenic speciation, and peripheral vascular disease in Blackfoot disease-hyperendemic villages in Taiwan. Toxicol Appl Pharmacol 206: 299–308. 10.1016/j.taap.2004.11.022.16039941
Tsuji, JS; Alexander, DD; Perez, V; Mink, PJ. (2014a). Arsenic exposure and bladder cancer: Quantitative assessment of studies in human populations to detect risks at low doses [Review]. Toxicology 317: 17–30. 10.1016/j.tox.2014.01.004.24462659
Tsuji, JS; Chang, ET; Gentry, PR; Clewell, HJ; Boffetta, P; Cohen, SM. (2019). Dose-response for assessing the cancer risk of inorganic arsenic in drinking water: the scientific basis for use of a threshold approach [Review]. Crit Rev Toxicol 49: 1–49. 10.1080/10408444.2019.1573804.30919727
Tsuji, JS; Garry, MR; Perez, V; Chang, ET. (2015). Low-level arsenic exposure and developmental neurotoxicity in children: A systematic review and risk assessment [Review]. Toxicology 337: 91–107. 10.1016/j.tox.2015.09.002.26388044
Tsuji, JS; Perez, V; Garry, MR; Alexander, DD. (2014b). Association of low-level arsenic exposure in drinking water with cardiovascular disease: A systematic review and risk assessment [Review]. Toxicology 323: 78–94. 10.1016/j.tox.2014.06.008.24953689
Turowski, JM. (2010). Probability distributions of bed load transport rates: A new derivation and comparison with field data. Water Resour Res 46. 10.1029/2009WR008488.
U.S. EPA (U.S. Environmental Protection Agency). (1993). Toxicological review of inorganic arsenic [EPA Report]. Washington, DC. http://www.epa.gov/NCEA/iris/subst/0278.htm.
U.S. EPA (U.S. Environmental Protection Agency). (1994). Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry [EPA Report]. (EPA600890066F). Research Triangle Park, NC. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=71993&CFID=51174829&CFTOKEN=25006317.
U.S. EPA (U.S. Environmental Protection Agency). (2002a). Implementation guidance for the arsenic rule: Drinking water regulations for arsenic and clarifications to compliance and new source contaminants monitoring [EPA Report]. (EPA-816-K-02-018). Washington, DC. https://nepis.epa.gov/Exe/ZyPDF.cgi?Dockey=P1009V6R.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2002b). A review of the reference dose and reference concentration processes [EPA Report]. (EPA630P02002F). Washington, DC. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2005a). Guidelines for carcinogen risk assessment [EPA Report]. (EPA630P03001F). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3-25-05.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2005b). Supplemental guidance for assessing susceptibility from early-life exposure to carcinogens [EPA Report]. (EPA/630/R-03/003F). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/supplemental-guidance-assessing-susceptibility-early-life-exposure-carcinogens.
U.S. EPA (U.S. Environmental Protection Agency). (2007). Arsenic in drinking water: Basic information. Available online at http://www.epa.gov/safewater/arsenic/basicinformation.html
U.S. EPA (U.S. Environmental Protection Agency). (2011). Exposure factors handbook: 2011 edition [EPA Report]. (EPA/600/R-090/052F). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, National Center for Environmental Assessment. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100F2OS.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2012). Benchmark dose technical guidance [EPA Report]. (EPA100R12001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/benchmark-dose-technical-guidance.
U.S. EPA (U.S. Environmental Protection Agency). (2015). Peer review handbook [EPA Report] (4th ed.). (EPA/100/B-15/001). Washington, DC: U.S. Environmental Protection Agency, Science Policy Council. https://www.epa.gov/osa/peer-review-handbook-4th-edition-2015.
U.S. EPA (U.S. Environmental Protection Agency). (2019). Exposure factors handbook chapter 3 (update): Ingestion of water and other select liquids [EPA Report]. (EPA/600/R-18/259F). Washington, DC. https://cfpub.epa.gov/ncea/efp/recordisplay.cfm?deid=343661.
U.S. EPA (U.S. Environmental Protection Agency). (2022). ORD staff handbook for developing IRIS assessments. (EPA 600/R-22/268). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Center for Public Health and Environmental Assessment. https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=356370.
U.S. EPA (U.S. Environmental Protection Agency). (2024a). Toxicological review of perfluorodecanoic acid (PFDA) and related salts (Final report, 2024). (EPA/635/R-24/172Fa). Washington, DC. https://iris.epa.gov/document/&deid=361797?
U.S. EPA (U.S. Environmental Protection Agency). (2024b). Workflow and modeling results and variable dictionary- Nov 21 2024 [EPA Report]. Washington, DC.
U.S. EPA (U.S. Environmental Protection Agency). (2025). Arsenic Dose-Response Modeling Results – January 2025. Retrieved from https://gaftp.epa.gov/CPHEA/Inorganic%20Arsenic%20Dose-Response%20Modeling%20Results%20%e2%80%93%20January%202025/
Vahter, M. (1981). Biotransformation of trivalent and pentavalent inorganic arsenic in mice and rats. Environ Res 25: 286–293. 10.1016/0013-9351(81)90030-X.7274192
Vahter, M. (1983) Metabolism of inorganic arsenic in relation to chemical form and animal species. (Doctoral Dissertation). Karolinska Institutet, Stockholm, Sweden.
Vahter, M. (1994). Species differences in the metabolism of arsenic compounds. Applied Organometallic Chemistry 8: 175–182. 10.1002/aoc.590080304.
Vahter, M. (1999a). Methylation of inorganic arsenic in different mammalian species and population groups [Review]. Sci Prog 82: 69–88. 10.1177/003685049908200104.10445007
Vahter, M. (1999b). Variation in human metabolism of arsenic. In WR Chappell; CO Abernathy; RL Calderon (Eds.), Arsenic exposure and health effects: Proceedings of the Third International Conference on Arsenic Exposure and Health Effects, July 12-15, 1998, San Diego, California (pp. 267–279). Amsterdam, Holland: Elsevier. 10.1016/b978-008043648-7/50031-5.
Vahter, M; Concha, G. (2001). Role of metabolism in arsenic toxicity [Review]. Pharmacol Toxicol 89: 1–5. 10.1034/j.1600-0773.2001.d01-128.x.
Vahter, M; Concha, G; Nermell, B; Nilsson, R; Dulout, F; Natarajan, AT. (1995a). A unique metabolism of inorganic arsenic in native Andean women. Eur J Pharmacol Environ Toxicol Pharmacol 293: 455–462. 10.1016/0926-6917(95)90066-7.
Vahter, M; Couch, R; Nermell, B; Nilsson, R. (1995b). Lack of methylation of inorganic arsenic in the chimpanzee. Toxicol Appl Pharmacol 133: 262–268. 10.1006/taap.1995.1150.7645022
Vahter, M; Envall, J. (1983). In vivo reduction of arsenate in mice and rabbits. Environ Res 32: 14–24. 10.1016/0013-9351(83)90187-1.6617606
Vahter, M; Friberg, L; Rahnster, B; Nygren, Å; Nolinder, P. (1986). Airborne arsenic and urinary excretion of metabolites of inorganic arsenic among smelter workers. Int Arch Occup Environ Health 57: 79–91. 10.1007/BF00381375.3949400
Vahter, M; Marafante, E. (1983). Intracellular interaction and metabolic fate of arsenite and arsenate in mice and rabbits. Chem Biol Interact 47: 29–44. 10.1016/0009-2797(83)90145-X.6640784
Vahter, M; Marafante, E. (1985). Reduction and binding of arsenate in marmoset monkeys. Arch Toxicol 57: 119–124. 10.1007/BF00343121.4026570
Vahter, M; Marafante, E. (1987). Effects of low dietary intake of methionine, choline or proteins on the biotransformation of arsenite in the rabbit. Toxicol Lett 37: 41–46. 10.1016/0378-4274(87)90165-2.3590229
Vahter, M; Marafante, E; Dencker, L. (1984). Tissue distribution and retention of 74As-dimethylarsinic acid in mice and rats. Arch Environ Contam Toxicol 13: 259–264. 10.1007/BF01055275.6742888
Vahter, M; Marafante, E; Lindgren, A; Dencker, L. (1982). Tissue distribution and subcellular binding of arsenic in Marmoset monkeys after injection of 74As-arsenite. Arch Toxicol 51: 65–77. 10.1007/BF00279322.
Vahter, M; Skröder, H; Rahman, SM; Levi, M; Hamadani, JD; Kippler, M. (2020). Prenatal and childhood arsenic exposure through drinking water and food and cognitive abilities at 10 years of age: A prospective cohort study. Environ Int 139: 105723. 10.1016/j.envint.2020.105723.32298878
Vaidya, N; Holla, B; Heron, J; Sharma, E; Zhang, Y; Fernandes, G; Iyengar, U; Spiers, A; Yadav, A; Das, S; Roy, S; Ahuja, CK; Barker, GJ; Basu, D; Bharath, RD; Hickman, M; Jain, S; Kalyanram, K; Kartik, K; Krishna, M; Krishnaveni, G; Kumaran, K; Kuriyan, R; Murthy, P; Papadopoulos Orfanos, D; Purushottam, M; Kurpad, SS; Singh, L; Singh, R; Subodh, BN; Toledano, M; Walter, H; Desrivières, S; Chakrabarti, A; Benegal, V; Schumann, G; (cVEDA), CoVtEDaA. (2023). Neurocognitive Analysis of Low-level Arsenic Exposure and Executive Function Mediated by Brain Anomalies Among Children, Adolescents, and Young Adults in India. JAMA Netw Open 6: e2312810. 10.1001/jamanetworkopen.2023.12810.37171822
Valentine, JL; Kang, HK; Spivey, G. (1979). Arsenic levels in human blood, urine, and hair in response to exposure via drinking water. Environ Res 20: 24–32. 10.1016/0013-9351(79)90082-3.499171
Valeri, L; Mazumdar, MM; Bobb, JF; Henn, BC; Rodrigues, E; Sharif, OIA; Kile, ML; Quamruzzaman, Q; Afroz, S; Golam, M; Amarasiriwardena, C; Bellinger, DC; Christiani, DC; Coull, BA; Wright, RO. (2017). The joint effect of prenatal exposure to metal mixtures on neurodevelopmental outcomes at 20-40 months of age: Evidence from rural Bangladesh. Environ Health Perspect 125: 067015. 10.1289/EHP614.28669934
Vandenberg, LN; Hauser, R; Marcus, M; Olea, N; Welshons, WV. (2007). Human exposure to bisphenol A (BPA) [Review]. Reprod Toxicol 24: 139–177. 10.1016/j.reprotox.2007.07.010.17825522
Vellar, OD. (1969) Nutrient losses through sweating: With special reference to the composition of whole body sweat during thermally induced profuse perspiration. (Doctoral Dissertation). University of Oslo, Oslo, Norway.
Velmurugan, G; Swaminathan, K; Mohanraj, S; Dhivakar, M; Veerasekar, G; Alexander, T; Cherian, M; Palaniswami, NG; Pradeep, T. (2020). Association of co-accumulation of arsenic and organophosphate insecticides with diabetes and atherosclerosis in a rural agricultural community: KMCH-NNCD-I study. Acta Diabetol 57: 1159–1168. 10.1007/s00592-020-01516-6.32314019
Velmurugan, G; Swaminathan, K; Veerasekar, G; Purnell, JQ; Mohanraj, S; Dhivakar, M; Avula, AK; Cherian, M; Palaniswami, NG; Alexander, T; Pradeep, T. (2018). Metals in urine in relation to the prevalence of pre-diabetes, diabetes and atherosclerosis in rural India. Occup Environ Med 75: 661–667. 10.1136/oemed-2018-104996.29674487
von Ehrenstein, OS; Guha Mazumder, DN; Hira-Smith, M; Ghosh, N; Yuan, Y; Windham, G; Ghosh, A; Haque, R; Lahiri, S; Kalman, D; Das, S; Smith, AH. (2006). Pregnancy outcomes, infant mortality, and arsenic in drinking water in West Bengal, India. Am J Epidemiol 163: 662–669. 10.1093/aje/kwj089.16524957
Wade, TJ; Xia, Y; Mumford, J; Wu, K; Le, XC; Sams, E; Sanders, WE. (2015). Cardiovascular disease and arsenic exposure in Inner Mongolia, China: a case control study. Environ Health 14: 35. 10.1186/s12940-015-0022-y.25889926
Wade, TJ; Xia, Y; Wu, K; Li, Y; Ning, Z; Le, XC; Lu, X; Feng, Y; He, X; Mumford, JL. (2009). Increased mortality associated with well-water arsenic exposure in Inner Mongolia, China. Int J Environ Res Public Health 6: 1107–1123. 10.3390/ijerph6031107.19440436
Wang, H; Li, X; Li, RJ; Yan, J; Lan, Z; Chen, J; Zhang, L. (2020a). Associations of exposure to metals with the risk of hypertension among an older population aged 40-75 years in rural southwest China. J Appl Toxicol 40: 1076–1086. 10.1002/jat.3968.32163192
Wang, SL; Chang, FH; Liou, SH; Wang, YC; Feng, BJ. (2005). Arsenic dose and its relation to cardiovascular risk among residents in middle Taiwan. Epidemiology 16: S25–S25.
Wang, W; Xie, Z; Lin, Y; Zhang, D. (2014). Association of inorganic arsenic exposure with type 2 diabetes mellitus: A meta-analysis [Review]. J Epidemiol Community Health 68: 176–184. 10.1136/jech-2013-203114.24133074
Wang, X; Gao, D; Zhang, G; Zhang, X; Li, Q; Gao, Q; Chen, R; Xu, S; Huang, L; Zhang, Y; Lin, L; Zhong, C; Chen, X; Sun, G; Song, Y; Yang, X; Hao, L; Yang, H; Yang, L; Yang, N. (2020b). Exposure to multiple metals in early pregnancy and gestational diabetes mellitus: A prospective cohort study. Environ Int 135: 105370. 10.1016/j.envint.2019.105370.31864020
Wang, X; Karvonen-Gutierrez, CA; Herman, WH; Mukherjee, B; Harlow, SD; Park, SK. (2020c). Urinary metals and incident diabetes in midlife women: Study of Women’s Health Across the Nation (SWAN). BMJ Open Diabetes Res Care 8: e001233. 10.1136/bmjdrc-2020-001233.
Wang, X; Karvonen-Gutierrez, CA; Herman, WH; Mukherjee, B; Harlow, SD; Park, SK. (2021a). Urinary Heavy Metals and Longitudinal Changes in Blood Pressure in Midlife Women: The Study of Women’s Health Across the Nation. Hypertension 78: 543–551. 10.1161/HYPERTENSIONAHA.121.17295.34148361
Wang, X; Karvonen-Gutierrez, CA; Herman, WH; Mukherjee, B; Park, SK. (2022). Metals and risk of incident metabolic syndrome in a prospective cohort of midlife women in the United States. Environ Res 210: 112976. 10.1016/j.envres.2022.112976.35202625
Wang, X; Mukherjee, B; Karvonen-Gutierrez, CA; Herman, WH; Batterman, S; Harlow, SD; Park, SK. (2020d). Urinary metal mixtures and longitudinal changes in glucose homeostasis: The Study of Women’s Health Across the Nation (SWAN). Environ Int 145: 106109. 10.1016/j.envint.2020.106109.32927284
Wang, X; Wu, Y; Sun, X; Guo, Q; Xia, W; Wu, Y; Li, J; Xu, S; Li, Y. (2021b). Arsenic exposure and metabolism in relation to blood pressure changes in pregnant women. Ecotoxicol Environ Saf 222: 112527. 10.1016/j.ecoenv.2021.112527.34311426
Wang, Y; Wang, K; Han, T; Zhang, P; Chen, X; Wu, W; Feng, Y; Yang, H; Li, M; Xie, B; Guo, P; Warren, JL; Shi, X; Wang, S; Zhang, Y. (2020e). Exposure to multiple metals and prevalence for preeclampsia in Taiyuan, China. Environ Int 145: 106098. 10.1016/j.envint.2020.106098.32916414
Wang, Y; Zhang, P; Chen, X; Wu, WW; Feng, YL; Yang, HL; Li, M; Xie, BJ; Guo, PG; Warren, JL; Shi, XM; Wang, SP; Zhang, YW. (2019). Multiple metal concentrations and gestational diabetes mellitus in Taiyuan, China. Chemosphere 237: 124412. 10.1016/j.chemosphere.2019.124412.31376695
Wang, YH; Yeh, SD; Shen, KH; Shen, CH; Juang, GD; Hsu, LI; Chiou, HY; Chen, CJ. (2009). A significantly joint effect between arsenic and occupational exposures and risk genotypes/diplotypes of CYP2E1, GSTO1 and GSTO2 on risk of urothelial carcinoma. Toxicol Appl Pharmacol 241: 111–118. 10.1016/j.taap.2009.08.008.19686770
Wasserman, GA; Liu, X; Loiacono, NJ; Kline, J; Factor-Litvak, P; van Geen, A; Mey, JL; Levy, D; Abramson, R; Schwartz, A; Graziano, JH. (2014). A cross-sectional study of well water arsenic and child IQ in Maine schoolchildren. Environ Health 13: 23. 10.1186/1476-069X-13-23.24684736
Wasserman, GA; Liu, X; Parvez, F; Ahsan, H; Factor-Litvak, P; Kline, J; van Geen, A; Slavkovich, V; Lolacono, NJ; Levy, D; Cheng, ZQ; Graziano, JH. (2007). Water arsenic exposure and intellectual function in 6-year-old children in Araihazar, Bangladesh. Environ Health Perspect 115: 285–289. 10.1289/ehp.9501.17384779
Wasserman, GA; Liu, X; Parvez, F; Ahsan, H; Factor-Litvak, P; van Geen, A; Slavkovich, V; Lolacono, NJ; Cheng, Z; Hussain, I; Momotaj, H; Graziano, JH. (2004). Water arsenic exposure and children’s intellectual function in Araihazar, Bangladesh. Environ Health Perspect 112: 1329–1333. 10.1289/ehp.6964.15345348
Waters, SB; Devesa, V; Del Razo, LM; Stylbo, M; Thomas, DJ. (2004a). Endogenous reductants support the catalytic function of recombinant rat cyt19, an arsenic methyltransferase. Chem Res Toxicol 17: 404–409. 10.1021/tx0342161.15025511
Waters, SB; Devesa, V; Fricke, MW; Creed, JT; Stýblo, M; Thomas, DJ. (2004b). Glutathione modulates recombinant rat arsenic (+3 oxidation state) methyltransferase-catalyzed formation of trimethylarsine oxide and trimethylarsine. Chem Res Toxicol 17: 1621–1629. 10.1021/tx0497853.15606138
Webb, DR; Sipes, IG; Carter, DE. (1984). In vitro solubility and in vivo toxicity of gallium arsenide. Toxicol Appl Pharmacol 76: 96–104. 10.1016/0041-008X(84)90032-2.6484996
Weiss, MC; Shih, YH; Bryan, MS; Jackson, BP; Aguilar, D; Hanis, CL; Argos, M; Sargis, RM. (2022). Relationships Between Urinary Metals and Diabetes Traits Among Mexican Americans in Starr County, Texas, USA. Biol Trace Elem Res 201: 529–538. 10.1007/s12011-022-03165-y.35247137
Wen, Y; Huang, S; Zhang, Y; Zhang, H; Zhou, L; Li, D; Xie, C; Lv, Z; Guo, Y; Ke, Y; Wu, T; Cheng, J. (2019). Associations of multiple plasma metals with the risk of ischemic stroke: A case-control study. Environ Int 125: 125–134. 10.1016/j.envint.2018.12.037.30716572
Wester, RC; Hui, X; Barbadillo, S; Maibach, HI; Lowney, YW; Schoof, RA; Holm, SE; Ruby, MV. (2004). In vivo percutaneous absorption of arsenic from water and CCA-treated wood residue. Toxicol Sci 79: 287–295. 10.1093/toxsci/kfh114.15056813
Wester, RC; Maibach, HI; Sedik, L; Melendres, J; Wade, M. (1993). In vivo and in vitro percutaneous absorption and skin decontamination of arsenic from water and soil. Fundam Appl Toxicol 20: 336–340. 10.1006/faat.1993.1043.8504907
Whitcomb, BW; Naimi, AI. (2020). Things Don’t Always Go as Expected: The Example of Nondifferential Misclassification of Exposure-Bias and Error. Am J Epidemiol 189: 365–368. 10.1093/aje/kwaa020.32080716
White, RF; Braun, JM; Kopylev, L; Segal, D; Sibrizzi, CA; Lindahl, AJ; Hartman, PA; Bucher, JR. (2022). NIEHS Report on Evaluating Features and Application of Neurodevelopmental Tests in Epidemiological Studies: NIEHS Report 01. Research Triangle Park (NC): National Institute of Environmental Health Sciences. 10.22427/NIEHS-01.
WHO (World Health Organization). (2000). Air quality guidelines for Europe (2nd ed.). Copenhagen, Denmark: World Health Organization, Regional Office for Europe. http://www.euro.who.int/en/health-topics/environment-and-health/air-quality/publications/pre2009/air-quality-guidelines-for-europe.
WHO (World Health Organization). (2011a). Evaluation of certain contaminants in food: Seventy-second report of the joint FAO/WHO expert committee on food additives (pp. 1–105, back cover). (WHO Technical Report Series, No. 959). http://whqlibdoc.who.int/trs/WHO_TRS_959_eng.pdf.
WHO (World Health Organization). (2011b). Safety evaluation of certain contaminants in food. (WHO Food Additives Series: 63. FAO JECFA Monographs 8). Geneva, Switzerland: prepared by the Seventy-second meeting of the Joint FAO/WHO Expert Committee on Food Additives (JECFA. http://whqlibdoc.who.int/publications/2011/9789241660631_eng.pdf.
Wilcox, AJ; Weinberg, CR; Basso, O. (2011). On the pitfalls of adjusting for gestational age at birth. Am J Epidemiol 174: 1062–1068. 10.1093/aje/kwr230.21946386
Wright, RO; Amarasiriwardena, C; Woolf, AD; Jim, R; Bellinger, DC. (2006). Neuropsychological correlates of hair arsenic, manganese, and cadmium levels in school-age children residing near a hazardous waste site. Neurotoxicology 27: 210–216. 10.1016/j.neuro.2005.10.001.16310252
Wu, C, -C; Huang, Y, -K; Chung, C, -J; Huang, C, -Y; Pu, Y, -S; Shiue, H, -S; Lai, L, -A; Lin, Y, -C; Su, C, -T; Hsueh, Y, -M. (2013). Polymorphism of inflammatory genes and arsenic methylation capacity are associated with urothelial carcinoma. Toxicol Appl Pharmacol 272: 30–36. 10.1016/j.taap.2013.05.019.23727622
Wu, F; Chen, Y; Navas-Acien, A; Garabedian, ML; Coates, J; Newman, JD. (2021). Arsenic Exposure, Arsenic Metabolism, and Glycemia: Results from a Clinical Population in New York City. Int J Environ Res Public Health 18. 10.3390/ijerph18073749.
Wu, F; Jasmine, F; Kibriya, MG; Liu, M; Wójcik, O; Parvez, F; Rahaman, R; Roy, S; Paul-Brutus, R; Segers, S; Slavkovich, V; Islam, T; Levy, D; Mey, JL; van Geen, A; Graziano, JH; Ahsan, H; Chen, Y. (2012). Association between arsenic exposure from drinking water and plasma levels of cardiovascular markers. Am J Epidemiol 175: 1252–1261. 10.1093/aje/kwr464.22534204
Wu, MM; Chiou, HY; Lee, TC; Chen, CL; Hsu, LI; Wang, YH; Huang, WL; Hsieh, YC; Yang, TY; Lee, CY; Yip, PK; Wang, CH; Hsueh, YM; Chen, CJ. (2010). GT-repeat polymorphism in the heme oxygenase-1 gene promoter and the risk of carotid atherosclerosis related to arsenic exposure. J Biomed Sci 17: 70. 10.1186/1423-0127-17-70.20796278
Xiao, L; Zhou, Y; Ma, J; Sun, W; Cao, L; Wang, B; Zhu, C; Yang, S; Wang, D; Yuan, J; Chen, W. (2018). Oxidative DNA damage mediates the association between urinary metals and prevalence of type 2 diabetes mellitus in Chinese adults. Sci Total Environ 627: 1327–1333. 10.1016/j.scitotenv.2018.01.317.30857096
Xu, L; Liu, Y; Zhao, Q; Du, H; Gao, Y; Bai, M; Lv, J; Guo, Y; Li, L; Sun, L; Lin, X; Chen, Z; Chen, Y; Zong, G. (2022). Urinary element profiles and associations with cardiometabolic diseases: A cross-sectional study across ten areas in China. Environ Res 205: 112535. 10.1016/j.envres.2021.112535.34896320
Xu, L; Polya, DA. (2021). Exploratory study of the association in the United Kingdom between hypertension and inorganic arsenic (iAs) intake from rice and rice products. Environ Geochem Health 43: 2505–2538. 10.1007/s10653-020-00573-8.32347515
Xu, L; Polya, DA; Li, Q; Mondal, D. (2020). Association of low-level inorganic arsenic exposure from rice with age-standardized mortality risk of cardiovascular disease (CVD) in England and Wales. Sci Total Environ 743: 140534. 10.1016/j.scitotenv.2020.140534.32659549
Xua, L; Suman, S; Sharma, P; Kumar, R; Singh, SK; Bose, N; Ghosh, A; Rahman, MM; Polya, DA; Mondal, D. (2021). Assessment of hypertension association with arsenic exposure from food and drinking water in Bihar, India. Ecotoxicol Environ Saf 223: 112572. 10.1016/j.ecoenv.2021.112572.34352571
Xue, J; Zartarian, V; Wang, SW; Liu, SV; Georgopoulos, P. (2010). Probabilistic modeling of dietary arsenic exposure and dose and evaluation with 2003-2004 NHANES data. Environ Health Perspect 118: 345–350. 10.1289/ehp.0901205.20194069
Yager, JW; Gentry, PR; Thomas, RS; Pluta, L; Efremenko, A; Black, M; Arnold, LL; McKim, JM; Wilga, P; Gill, G; Choe, K, -Y; Clewell, HJ. (2013). Evaluation of gene expression changes in human primary uroepithelial cells following 24-hr exposures to inorganic arsenic and its methylated metabolites. Environ Mol Mutagen 54: 82–98. 10.1002/em.21749.23192986
Yamauchi, H; Takahashi, K; Yamamura, Y. (1986). Metabolism and excretion of orally and intraperitoneally administered gallium arsenide in the hamster. Toxicology 40: 237–246. 10.1016/0300-483X(86)90056-9.3750324
Yamauchi, H; Yamamura, Y. (1979). Dynamic change of inorganic arsenic and methylarsenic compounds in human urine after oral intake as arsenic trioxide. Ind Health 17: 79–83. 10.2486/indhealth.17.79.
Yamauchi, H; Yamamura, Y. (1984). Metabolism and excretion of orally administered dimethylarsinic acid in the hamster. Toxicol Appl Pharmacol 74: 134–140. 10.1016/0041-008X(84)90279-5.6729818
Yang, K; Xun, P; Carnethon, M; Carson, AP; Lu, L; Zhu, J; He, K. (2019). Low to moderate toenail arsenic levels in young adulthood and incidence of diabetes later in life: Findings from the CARDIA Trace Element study. Environ Res 171: 321–327. 10.1016/j.envres.2019.01.035.30711733
Yang, Q; Liu, Y; Liu, L; Zhang, L; Lei, J; Wang, Q; Hong, F. (2022). Exposure to multiple metals and diabetes mellitus risk in dong ethnicity in China: from the China multi-ethnic cohort study. Environ Geochem Health 45: 2435–2445. 10.1007/s10653-022-01366-x.35986857
Yang, T, seYen; Hsu, LI; Chen, H, uiChi; Chiou, HY, i; Hsueh, Y, uMei; Wu, MM; Chen, C, hiL; Wang, YH; Liao, Y, aT; Chen, CJ, en. (2013). Lifetime risk of urothelial carcinoma and lung cancer in the arseniasis-endemic area of Northeastern Taiwan. J Asian Earth Sci 77: 332–337. 10.1016/j.jseaes.2013.03.023.
Ye, X; Zhou, X; Wong, LY; Calafat, AM. (2012). Concentrations of bisphenol a and seven other phenols in pooled sera from 3-11 year old children: 2001-2002 national health and nutrition examination survey. Environ Sci Technol 46: 12664–12671. 10.1021/es303109c.23102149
Yen, CC; Chen, HH; Hsu, YT; Tseng, CJ; Lin, CH. (2022). Effects of heavy metals in acute ischemic stroke patients: A cross-sectional study. Medicine (Baltimore) 101: e28973. 10.1097/MD.0000000000028973.35244065
Yland, JJ; Wesselink, AK; Lash, TL; Fox, MP. (2022). Misconceptions About the Direction of Bias From Nondifferential Misclassification. Am J Epidemiol 191: 1485–1495. 10.1093/aje/kwac035.35231925
Yoshida, K; Inoue, Y; Kuroda, K; Chen, H; Wanibuchi, H; Fukushima, S; Endo, G. (1998). Urinary excretion of arsenic metabolites after long-term oral administration of various arsenic compounds to rats. J Toxicol Environ Health A 54: 179–192. 10.1080/009841098158890.9643871
Yu, D. (1999). A physiologically based pharmacokinetic model of inorganic arsenic. Regul Toxicol Pharmacol 29: 128–141. 10.1006/rtph.1999.1282.10341143
Zakharyan, R; Wu, Y; Bogdan, GM; Aposhian, HV. (1995). Enzymatic methylation of arsenic compounds: Assay, partial purification, and properties of arsenite methyltransferase and monomethylarsonic acid methyltransferase of rabbit liver. Chem Res Toxicol 8: 1029–1038. 10.1021/tx00050a006.8605285
Zakharyan, RA; Aposhian, HV. (1999). Enzymatic reduction of arsenic compounds in mammalian systems: The rate-limiting enzyme of rabbit liver arsenic biotransformation is MMA(V) reductase. Chem Res Toxicol 12: 1278–1283. 10.1021/tx9901231.10604879
Zakharyan, RA; Ayala-Fierro, F; Cullen, WR; Carter, DM; Aposhian, HV. (1999). Enzymatic methylation of arsenic compounds: VII. Monomethylarsonous acid (MMAIII) is the substrate for MMA methyltransferase of rabbit liver and human hepatocytes. Toxicol Appl Pharmacol 158: 9–15. 10.1006/taap.1999.8687.10387927
Zakharyan, RA; Sampayo-Reyes, A; Healy, SM; Tsaprailis, G; Board, PG; Liebler, DC; Aposhian, HV. (2001). Human monomethylarsonic acid (MMA(V)) reductase is a member of the glutathione-S-transferase superfamily. Chem Res Toxicol 14: 1051–1057. 10.1021/tx010052h.11511179
Zakharyan, RA; Wildfang, E; Aposhian, HV. (1996). Enzymatic methylation of arsenic compounds: III. The marmoset and tamarin, but not the rhesus, monkeys are deficient in methyltransferases that methylate inorganic arsenic. Toxicol Appl Pharmacol 140: 77–84. 10.1006/taap.1996.0199.
Zartarian, V; Bahadori, T; Mckone, T. (2005). Adoption of an official ISEA glossary. J Expo Anal Environ Epidemiol 15: 1–5. 10.1038/sj.jea.7500411.15562291
Zhang, J; Xu, C; Guo, Y; Jin, X; Cheng, Z; Tao, Q; Liu, L; Zhan, R; Yu, X; Cao, H; Tao, F; Sheng, J; Wang, S. (2022a). Increased hypertension risk for the elderly with high blood levels of strontium and lead. Environ Geochem Health 45: 1877–1888. 10.1007/s10653-022-01317-6.35727389
Zhang, J; Yin, H; Zhu, X; Xiang, R; Miao, Y; Zhang, Y; Song, Y; Chen, J; Zhang, L. (2022b). Effects of multi-metal exposure on the risk of diabetes mellitus among people aged 40-75 years in rural areas in southwest China. J Diabetes Investig 13: 1412–1425. 10.1111/jdi.13797.
Zhang, Q; Hou, Y; Wang, D, a; Xu, Y; Wang, H; Liu, J; Xia, L; Li, Y; Tang, N; Zheng, Q; Sun, G. (2020). Interactions of arsenic metabolism with arsenic exposure and individual factors on diabetes occurrence: Baseline findings from Arsenic and Non-Communicable disease cohort (AsNCD) in China. Environ Pollut 265: 114968. 10.1016/j.envpol.2020.114968.32806398
Zhang, Z; Zhao, S; Wu, H; Qin, W; Zhang, T; Wang, Y; Tang, Y; Qi, S; Cao, Y; Gao, X. (2022c). Cross-sectional study: Relationship between serum trace elements and hypertension. J Trace Elem Med Biol 69: 126893. 10.1016/j.jtemb.2021.126893.34798511
Zhong, Q, i; Zhang, C, hi; Zhang, Q; Jiang, CX; Qin, Q, iR; Chen, J; Liang, L; Huang, F, en. (2019). Arsenic exposure and incident hypertension of adult residents living in rural areas along the Yangtze River, Anhui, China. J Occup Environ Med 61: 271–277. 10.1097/JOM.0000000000001511.30507786
Zhou, M; Zhao, E; Huang, R. (2022). Association of urinary arsenic with insulin resistance: Cross-sectional analysis of the National Health and Nutrition Examination Survey, 2015-2016. Ecotoxicol Environ Saf 231: 113218. 10.1016/j.ecoenv.2022.113218.35065504