# APPENDIX G SUMMARY OF OTHER AGENCY CONCLUSIONS

In addition to EPA (U.S. EPA, 1993, 2002a; McGeer et al., 2004), other national and international health agencies have also assessed inorganic arsenic. Toxicity information on inorganic arsenic has been evaluated by the Agency for Toxic Substances and Disease Registry (ATSDR, 2007, 2016), the World Health Organization (WHO, 2000, 2011a, b; IARC, 2004a), National Institute for Occupational Safety and Health (NIOSH, 2018), Occupational Safety and Health Administration (OSHA, 2005), Food and Drug Administration (FDA, 2005, 2020; CFSAN, 2023), Health Canada (Health Canada, 2006), Dutch National Institute for Public Health and the Environment (RIVM, 2001), and the International Agency for Research on Cancer (IARC, 2012), and the National Toxicology Program (NTP, 2016). EPA used these assessments to ensure that the literature search captured pertinent studies and to identify key issues and health outcomes that have been previously evaluated. Toxicity values and their bases from these assessments are presented in Table G-1. It is important to recognize that these assessments may have been prepared at different times, for different purposes, using different guidelines and methods. In addition, newer studies may be included in the IRIS assessment.

Table G-1 Health assessments and regulatory limits by other national and international health agencies for inorganic arsenic

Organization | Toxicity value
Agency for Toxic Substances and Disease Registry (ATSDR, 2007, 2016) | Acute-duration oral MRL of 0.0005 mg/kg/d; Chronic-duration oral MRL of 0.0003 mg/kg/d
Dutch National Institute for Public Health and the Environment (RIVM, 2001) | TDI of 1.0 µg/kg/d for chronic oral exposures and 1.0 µg/m^3^ for chronic inhalation exposures
Food and Drug Administration (FDA, 2005, 2020; CFSAN, 2023) | Bottled drinking water level of 0.01 mg/L; “action level” of 10 µg/L in apple juice; “action level” of 100 µg/L in rice and rice products
Health Canada (Health Canada, 2006) | MAC of 0.01 mg/L
International Agency for Research on Cancer (IARC, 2012) | Carcinogenic to humans (Group 1)
National Institute of Occupational Safety and Health (NIOSH, 2018) | REL (15 min ceiling limit) of 0.002 mg/m^3^; IDLH of 5 mg/m^3^
National Toxicology Program (NTP, 2016) | Known to be a human carcinogen
Occupational Safety and Health Administration (OSHA, 2005) | PEL (8-hr TWA) of 10 µg/m^3^
U.S. Environmental Protection Agency | RfD of 0.0003 mg/kg/d U.S. EPA (1993); Cancer slope factor of 1.5 mg/kg/d U.S. EPA (1993); Inhalation unit risk of 0.0043 µg/m^3^ U.S. EPA (1993); DWEL of 0.01 mg/L McGeer et al. (2004); MCLG of zero U.S. EPA (2002a); MCL of 0.01 mg/L U.S. EPA (2002a)
World Health Organization (WHO, 2000, 2011b; IARC, 2004b) | Air quality guidelines of 1.5 × 10^−3^-unit risk; Drinking water quality guidelines of 0.01 mg/L