# APPENDIX F SUMMARY OF PUBLIC AND EXTERNAL PEER REVIEW COMMENTS AND EPA’S DISPOSITION

The IRIS Toxicological Review of Inorganic Arsenic has undergone a formal external peer review by the SAB Chemical Assessment Advisory Committee (CAAC) in accordance with U.S. Environmental Protection Agency (EPA) guidance on peer review (U.S. EPA, 2015). As part of this process the IRIS Toxicological Review of Inorganic Arsenic was released for public comment on October 16, 2023, with a response deadline of December 16, 2023. BMD Model Code and Modeling Results were released for public comment on December 29, 2023, with a response deadline of January 16, 2024. A public, external peer-review meeting of the SAB CAAC was held January 24, 25, and 26, 2024, which included another opportunity for public comment.

The external peer reviewers were tasked with providing written answers to questions on the overall assessment approach, key conclusions, and areas of scientific controversy or uncertainty. Comments made by the external peer reviewers and public commenters, as well as EPA’s responses to these comments, are arranged by charge question in this Appendix. In addition to providing specific tiered comments for EPA to address (see below), the SAB report included descriptions of the panel’s disposition on each charge question. Abbreviated summaries of these descriptions (generally using the report’s topic paragraphs or topic sentences) are provided in each section below; please consult the final peer review report for the full text: Peer Review Report (https://sab.epa.gov/ords/sab/f?p=114:0:11294581818936:APPLICATION_PROCESS=REPORT_DOC:::REPORT_ID:1136). External Peer Reviewers were asked to prioritize their comments into tiers to indicate their relative importance as follows. The prioritization instructions are duplicated below from the IRIS iAs charge questions to the peer reviewers, which can be found in the public EPA docket (EPA-HQ-ORD-2012-0830 (https://www.regulations.gov/docket/EPA-HQ-ORD-2012-0830)).

Tier 1: Recommended Revisions–Key major recommendations necessary for strengthening the scientific basis for the IRIS Toxicological Review of Inorganic Arsenic. The implication of such key Tier 1 recommendations is that the assessment conclusions are not adequately supported without addressing the recommendations and need to be reconsidered or better substantiated. For Tier 1 recommendations, please describe the specific revisions necessary to modify or better substantiate the most scientifically appropriate assessment conclusions.

Tier 2: Suggestions–Recommendations that are encouraged to strengthen the scientific analyses and conclusions in the IRIS Toxicological Review of Inorganic Arsenic. It is understood that other factors (e.g., timeliness) may also be considered before deciding to address and/or incorporate Tier 2 suggestions. For Tier 2 recommendations, please provide specific suggestions to strengthen the scientific basis for assessment conclusions or improve the clarity of the analyses and presentation.

Tier 3: Future Considerations–Scientific exploration that might inform future work. These recommendations are outside the immediate scope or needs of the current document under review but could inform future Toxicological Reviews or research efforts.

Appendix F lists all Tier 1 Recommendations, Tier 2 Suggestions, and Tier 3 Future Considerations. Public comments submitted to the EPA docket are included within each relevant charge question topic area. There is also an “Additional Public Comments on Hazard Identification” section for comments on hazard identification not covered in the charge questions or highlighted in the SAB report. When comments from the public and peer review panel on a topic differed, the recommendations of the external peer-review panel are prioritized. When comments from the public and peer review panel are similar, comments are presented under both the “SAB Peer Reviewer Comments” and “Public Comments” sections. Responses for the similar public comment, in general, will also refer to the response provided under the peer review panel comment. In many cases, the public comments have been synthesized and paraphrased for brevity, both in this Appendix and in the summary document provided as a courtesy to the external peer review panel. Please see docket (EPA-HQ-ORD-2012-0830) for both this summary document and the full text of the submitted public comments. External peer reviewer and public comments regarding requests for editorial or grammatical corrections have been made throughout the assessment as appropriate; these comments and responses have not been tracked in this Appendix. Section, table, and figure call-outs mentioned in SAB and public comments refer to the external peer review draft of the assessment.

## F.1 CHARGE QUESTIONS 1 AND 2–SYSTEMATIC REVIEW METHODS AND DOCUMENTATION

1) The IRIS Toxicological Review of Inorganic Arsenic describes and applies a systematic review protocol for identifying and screening pertinent studies. The protocol is described in brief detail in Section 1.5.1 (Literature Searching and Screening) and in full detail in Appendix A (Updated Problem Formulation and Protocol for Inorganic Arsenic IRIS Assessment). If applicable, please identify additional peer-reviewed studies of inorganic arsenic that the assessment should incorporate. ^43^
  As recommended in the 2019 National Academies of Sciences, Engineering, and Medicine (NASEM) review of the Inorganic Arsenic protocol, bladder cancer and lung cancer were accepted as hazards and only considered for the ability to update dose-response analyses. Similarly, the following health outcomes were included for evaluation of both hazard and, as appropriate, dose-response analyses: diseases of the circulatory system, diabetes, pregnancy outcomes, and developmental neurotoxicity. For these latter health effects, the Toxicological Review provides an overview of individual study evaluations, and the results of those evaluations are made available in the Health Assessment Workplace Collaborative linked here HAWC. Note that a “HAWC FAQ for assessment readers” document, linked here (scroll to the bottom of the page, and the document is available for download under “attachments”), is intended to help the reviewer navigate this on-line resource.

Please comment on whether the study confidence conclusions for the Inorganic Arsenic studies are scientifically justified and clearly described, considering the important methodological features of the assessed outcomes. Please indicate any study confidence conclusions that are not justified and explain any alternative study evaluation decisions.

Results from individual inorganic arsenic studies are presented and synthesized in the health outcomes sections. Please comment on whether the presentation and analysis of study results are clear, appropriate, and effective to allow for scientifically supported syntheses of the findings across sets of studies.

### F.1.1 SAB Peer Reviewer Comments on Systematic Review and Documentation (Charge Question 1)

For charge question 1, the SAB panel found “the IRIS Toxicological Review of Inorganic Arsenic has been highly responsive to previous recommendations [e.g., (NRC, 2013; NASEM, 2019)], focusing on epidemiological studies, databases that are appropriate, and good description of population, exposures, comparators, and outcomes (PECO). The focus on the chronic exposure and the inclusion of both studies with environmental samples and biomarkers of arsenic exposure is appropriate. Given the magnitude of the iAs literature, the focus on priority outcomes of bladder cancer, lung cancer, cardiovascular outcomes, diabetes, pregnancy and birth outcomes, and neurodevelopmental effects seems reasonable although some outcomes were not pursued regarding the 2013 and 2019 recommendations (e.g., skin lesions, skin cancer, renal and liver cancers, nonmalignant respiratory disease).” The report includes additional panel perspectives on EPA’s inclusion decisions and the identified supplemental materials (see full report for details). The panel also highlighted several comments relevant to the systematic review approach provided under charge questions 2, 3, and 4 (summarized below in Sections F.1.2 and F.1.3, F.2, and F.3, respectively), and that additional studies are provided under subsequent charge questions.

The SAB panel’s tiered comments on Charge Question 1 were:

- 0 Tier 1 Recommended Revision
- 0 Tier 2 Suggested Revisions
- 2 Tier 3 Future Consideration

#### Tier 1 Recommendations for Charge 1

- The reviewers had no Tier 1 recommendations.

#### Tier 2 Suggestions for Charge 1

- The reviewers had no Tier 2 suggestions.

#### Tier 3 Future Considerations for Charge 1

[underlined: SAB Future Consideration (1 of 2 Tier 3 for Charge 1):] EPA could augment the literature search by looking for the “cited by” references for each screened study to see if any articles are identified that were not retrieved by systematically querying the health literature databases.

[underlined: EPA Response:] The type of search described in this recommendation is conducted by the IRIS Program on a case-by-case basis [(U.S. EPA, 2022), Section 2.3.3]. When performed, such searches are typically limited to the key studies that meet the assessment PECO criteria and directly inform the assessment’s conclusions. The feasibility of conducting such a “snowballing” search is reduced for very large evidence bases, such as the one available for inorganic arsenic (~540 studies). Concern for missing critical studies is mitigated because the draft development and finalization process for IRIS assessments includes multiple opportunities for references to be identified by content experts, e.g., Agency/Interagency review, multiple public comment opportunities, and external peer review.

[underlined: SAB Future Consideration (2 of 2 Tier 3 for Charge 1):] Consider conducting a sensitivity analysis for ischemic heart disease outcomes that includes the Aarhus, Denmark sub-study in Monrad et al. (2017).

[underlined: EPA Response:] The Monrad et al. (2017) study was not included in the main dose-response analysis given that the effect measure reported in that study is an incidence rate ratio and not a relative risk. Thus, this study was not suitable for inclusion in the hierarchical Bayesian dose-response meta-analysis that combines cohort (relative risk) and case-control (odds ratio) studies.

### F.1.2 SAB Peer Reviewer Comments on Systematic Review and Documentation (Charge Question 2.a)

The report states (under charge question 1), “As indicated in charge question #2, for cancers, it was assumed that causal relationships exist, and the focus was to “update the quantitative risk estimates” (pages ES-1, line 27). This seems reasonable to the committee and no changes are recommended. The focus on medium and high-confidence studies is methodologically appropriate to ensure the most valid pooled-estimates for population inference.” For charge question 2a, the report continues, “EPA has produced an excellent IRIS review of iAs toxicity by providing confidence that the studies are scientifically justified and presented clearly. The confidence conclusions are justified and strengthened by using the wealth of human epidemiological data in the conclusions of the hazard assessment for the cancer and noncancer disease endpoints. The epidemiological database includes studies with a broad range of exposures supporting hazard and dose-response analyses. Thus, mode of action (MOA) considerations are limited to establishing the biological plausibility for the health outcomes of interest. The systematic review approach and the methods used by EPA for including/excluding studies in the draft IRIS for iAs are described in detail and presented in a consistent and logical manner across the four health outcomes listed in the charge question. Overall, the systematic approach used by EPA for including/excluding studies for analyses had several strengths compared to those used in past IRIS documents (e.g., Fig 1-1) and adhered to more recent NASEM recommendations (NASEM, 2019).” The panel included several recommendations and suggestions as tiered comments for EPA to improve the clarity of the search strategies and study confidence rankings (see full report for details). The report did emphasize “An important issue raised in evaluating the evidence is whether the EPA could include discussion of MOA and mechanistic studies to improve confidence of the plausibility of the hazard identification and identification of points of departure at low levels of iAs exposure. The exclusive use of human data to establish hazard and dose-response relationships is sufficient to support the conclusions and is desired to reduce uncertainty in the outcome of the analyses. In vitro and in vivo animal and human mechanistic data could be used to demonstrate the MOA and pathogenic mechanisms for iAs-promoted cardiovascular disease. However, the animal data should not be combined with the human data in the dose-response analyses as it would unnecessarily raise uncertainty in the RfD due to requiring the factoring of cross-species uncertainty.”

The SAB panel’s tiered comments on Charge Question 2.a were:

- 3 Tier 1 Recommended Revisions
- 3 Tier 2 Suggested Revisions
- 0 Tier 3 Future Considerations

#### Tier 1 Recommendation for Charge 2.a

[underlined: SAB Recommendation (1 of 3 Tier 1 for Charge 2.a):] EPA should include tables for studies that were considered low confidence or uninformative for assessing the study confidence conclusions, similar to what was done for medium and high confidence studies (i.e., in HAWC and as supplemental materials/appendices). Literature trees should be expanded to include low and uninformative studies.

[underlined: EPA Response:] Study evaluation heatmaps for low and uninformative studies are now available in HAWC and Section B.4. Literature trees have been expanded in HAWC to include sub-outcome tagging for low and uninformative studies (see Figures 3-3, 3-22, 3-27, 3-39).

[underlined: SAB Recommendation (2 of 3 Tier 1 for Charge 2.a):] EPA should clarify that the individual study evaluations were not outcome-specific and were not sufficiently refined to the topic. “It is also recommended that EPA describe how a study can have low confidence in the source of modifiers and covariates and still receive high and medium confidence for the dose-response analysis.” EPA should clarify statements on page 1-9 that suggests that some of the new data did not undergo study evaluation but was only considered for dose-response criteria, as well as clarify the workflow and results.

[underlined: EPA Response:] Study evaluations for the arsenic assessment incorporates outcome-specific considerations, as is standard for IRIS assessments (U.S. EPA, 2022). A new subsection, “Impact of Other Factors,” in Section 1.6.2, was added and contains a discussion of some of the common confounders considered for each of the four health outcomes described in Evidence Synthesis (diseases of the circulatory system; diabetes; fetal, newborn, and infant health; neurodevelopmental effects).

Clarifying text has been added in Section 1.6.2: “Study evaluations are holistic judgments based on all domains that are considered. A judgment of probably high risk of bias in one domain does not necessarily mean that the entire study is low confidence or unsuitable for dose-response. The study evaluations are aimed at discerning limitations that could substantively change a result presented in the study or the interpretation of that result, also considering the expected direction of the bias. There are no defined weights for the domains, and study reviewers are responsible for applying expert judgment to make the determination of overall study confidence rating.” For medium confidence studies, possible deficiencies or concerns are identified, but the limitations are considered unlikely to have a significant impact on the study results or their interpretation. Because the process of study evaluation inherently involves expert judgment, each study is independently reviewed by at least two epidemiologists and any differences of opinions on domain judgements are resolved through discussion or consultation with other epidemiologists. With regard to confounders, the same reasoning applies even if a study does not assess all covariates known to have impact on the outcome, or has low confidence in the source of the covariates, it does not mean there is inherent bias. The most common reason that studies were downgraded in a domain related to confounding was lack of information on whether a validated questionnaire was used to collect information on covariates. However, the issue of whether or not a questionnaire is validated wasn’t expected to have a substantial impact on bias in the studies or rise to the level of impacting the overall confidence level.

EPA has added text in Section 1.6.1 (includes page 1-9 of the prior version of the assessment as referenced by the SAB) to clarify workflows for diseases of the circulatory system (DCS); diabetes; fetal, newborn and infant health; and neurodevelopmental effects. EPA had already characterized the strength of the evidence base for DCS and diabetes as robust (based on studies identified up to 2019). Thus, findings from new studies were not likely to alter the hazard conclusion. For these outcomes, if a study from the recent literature search update made it through study selection for dose-response, it then underwent study evaluation to ensure that it was medium or high confidence. This allowed EPA to prioritize efforts for study evaluation for only those studies that could be considered suitable for dose-response based on study design characteristics. EPA characterized the strength of the evidence base to be moderate for fetal, newborn, and infant health outcomes and neurodevelopmental effects (based on studies identified up to 2019). For this reason, studies identified in the 2022 update underwent risk of bias evaluation to determine if new studies would change the evidence synthesis hazard conclusion from moderate. Subsequently, overall medium or high confidence studies from the 2022 update underwent a screening process to evaluate suitability for dose-response based on study design characteristics (and key aspects of study evaluation).

[underlined: SAB Recommendation (3 of 3 Tier 1 for Charge 2.a):] EPA should include mechanistic studies to increase evidence for the plausibility of the outcomes for human dose-response relationship and RfD determination for cardiovascular disease. “The SAB suggests a review of the literature where mouse models respond with the preclinical signs of human disease within the low range of human exposure. Examples should include dose-response studies in the mouse model of atherosclerosis that demonstrate a threshold for chronic dosing near 10 μg/L (Makhani et al., 2018). Vascular remodeling and endothelial dysfunction are observed with thresholds between 1 and 10 μg/L (Straub et al., 2008; Soucy et al., 2003). The likely mechanism is reactive oxygen species generation as a result of iAs chronically activating endothelial and cardiac cell NADPH oxidases and decreasing nitric oxide bioavailability (Straub et al., 2008). Generation of NADPH derived superoxide and hydrogen peroxide deprives the vasculature of nitric oxide needed to dilate vessels, suppress inflammation, and reduce the inflammatory cell infiltration that is the mechanism for atherogenesis. At human relevant chronic dosing, iAs also alters arginine metabolism to reduce nitric oxide causing a pathogenic plasma asymmetric dimethylarginine (ADMA) profile (Dheer et al., 2015), a known risk factor for cardiac disease in humans (Osorio-Yáñez et al., 2013). Other subchronic and chronic rodent studies with exposures less than 100 μg/L find pathogenic structural cardiac remodeling and gene expression (Soucy et al., 2005; Hays et al., 2008). Thus, as suggested in NRC 2013, animal data could be included in the hazard and dose-response assessment to provide enhanced evidence for plausibility and MOA information that would strengthen the certainty of the RfD for cardiovascular disease. However, the SAB agrees that animal data should not be used in determining human dose-response relationships given the vast amount of relevant epidemiologic data.”

[underlined: EPA Response:] Additional text has been added in Section 3.2.1 that includes a discussion of studies that provide support for biological plausibility and strengthen the confidence of the hazard conclusion that supports derivation of an RfD for CVD. Experimental animal studies used to investigate cardiovascular disease have often used arsenic concentrations greater than what is environmentally relevant (i.e., ppm vs. ppb) (Srivastava et al., 2009) or the duration of the studies is short-term (e.g., 2–8 weeks) (Soucy et al., 2003; Soucy et al., 2005; Hays et al., 2008). However, these studies do provide mechanistic evidence that arsenic is able to stimulate vascular growth, angiogenesis, and stimulate the production of reactive oxygen species (ROS). The additional text added to Section 3.2.1 describes the results from the studies mentioned by SAB to better characterize and integrate the mechanistic evidence for the observed cardiovascular effects in epidemiology studies. In addition text has been added to the revised assessment to describe the evidence from humanized and specialized mouse models such as the Apoe -/- and p47PHOX knock-out strains that have provided information that environmentally relevant levels of arsenic are able to increase the number and size of atherosclerotic lesions (Makhani et al., 2018; Lemaire et al., 2011) and capillarization and vessel remodeling (Straub et al., 2008). This information strengthens the weight of evidence that inorganic arsenic exposure even at low levels increases risk for atherosclerosis (Straub et al., 2008; Srivastava et al., 2009; Simeonova et al., 2003; Makhani et al., 2018; Lemaire et al., 2011). The evidence provided from these models supports the biological plausibility and adds to the weight of evidence that environmentally relevant levels of inorganic arsenic increase the risk for cardiovascular disease in humans.

#### Tier 2 Suggestions for Charge 2.a

[underlined: SAB Suggestion (1 of 3 Tier 2 for Charge 2.a):] EPA should clarify whether or why regression analysis did not include dose-response data above 100 µg/L when well water in the U.S. ranges to more than1,000 µg/L in the executive summary (lines 27–29).

[underlined: EPA Response:] The regression analysis included data above 100 µg/L. Dose response data for all studies that underwent study selection for dose-response and were considered suitable were included in the hierarchical Bayesian dose-response analysis (except for situations where individual study high doses were dropped for the purpose of model fit, see Section C.1.2). These doses were often in the range of 1 to 100 μg/L (see Section ES.2). However, higher doses were included in the dose-response analyses when individual studies had high doses that exceeded 100 μg/L.

[underlined: SAB Suggestion (2 of 3 Tier 2 for Charge 2.a):] “EPA should eliminate all references to discredited dogma that animal and cell-based models are insensitive to pathogenesis and disease promotion. This is not true for iAs promoted cardiovascular disease and likely cancer promotion in studies that adhere to human relevant dosing.”

[underlined: EPA Response:] EPA’s intent is not to suggest animal and cell-based models are generally insensitive to pathogenesis and disease progression. Animal and cell-based studies were considered in the context of having a large evidence base of general population human studies suitable for dose-response. In the analyses described in the Updated Problem Formulation and Protocol for the Inorganic Arsenic Assessment (see Section 2.3.2 and Appendix A), EPA observed that in vitro studies are often conducted at high concentrations (>1uM), which limits their use in drawing conclusions about the shape of the dose response at low environmental levels. However, in vitro studies have been instrumental in helping to elucidate MOAs associated with arsenic toxicity, such as reactive oxygen species (ROS) generation and oxidative stress response, As(III) binding to thiol groups and inhibition of key enzymes, epigenomics, cytotoxicity and regenerative proliferation, As(V) inhibition of oxidative phosphorylation (As(V) structural analog of phosphate), and endocrine disruption (see MOA analysis in appendix A of the protocol). EPA agrees that animal and in vitro models can be informative for understanding pathogenesis and disease promotion, such as the role of ROS production in arsenic induced angiogenesis and vascular remodeling (Straub et al., 2008; Lau et al., 2013; Barchowsky et al., 1996; Barchowsky et al., 1999). Because rodents have a higher rate of arsenic metabolism and urinary clearance than humans (Vahter, 1999a; Vahter and Concha, 2001; EFSA, 2009; Douillet et al., 2023; ATSDR, 2007), they are often dosed at arsenic concentrations greater than what is environmentally relevant (i.e., ppm vs. ppb). In addition, the duration of the studies is limited to short term or subchronic duration studies. This limits the utility of the data coming from such models to inform human health or use in developing chronic toxicity values (EFSA, 2009; ATSDR, 2007) especially given the abundance of available epidemiological data, including at the low levels of arsenic exposure. However, humanized, and specialized mouse models such as the Apoe -/- and p47PHOX knock-out have provided information that environmentally relevant levels of arsenic are able to increase the number and size of atherosclerotic lesions (Srivastava et al., 2009; Simeonova et al., 2003; Makhani et al., 2018; Lemaire et al., 2011) and capillarization and vessel remodeling (Straub et al., 2008). Text has been updated in Section 3.2.1 to better reflect these advancements in the field and to clarify that the evidence provided from these models supports the biological plausibility and adds to the weight of evidence that environmentally relevant levels of inorganic arsenic increase the risk for cardiovascular disease in humans.

[underlined: SAB Suggestion (3 of 3 Tier 2 for Charge 2.a):] EPA should improve the quality and increase resolution of Figures to improve legibility and clarity.

[underlined: EPA Response:] Images in the assessment text are meant to be thumbnails only because many are too long to present on a single page. Figures in the assessment are hyperlinked to HAWC where they can be viewed with improved resolution and quality.

#### Tier 3 Future Considerations for Charge 2.a

The reviewers had no Tier 3 future considerations.

### F.1.3 SAB Peer Reviewer Comments on Systematic Review and Documentation (Charge Question 2.b)

For question 2b, “The SAB agrees that the overall presentation of the results, including the figures and tables, is laid out reasonably. However, it is not easy to follow the sequence of results from individual studies from one section to another and the corresponding results in the figures and text. There are ways they could be more effectively organized and described.” The panel included recommendations and suggestions as tiered comments for EPA to address as improvements in this area (see full report for details).

The SAB panel’s tiered comments on Charge Question 2.b were:

- 4 Tier 1 Recommended Revisions
- 6 Tier 2 Suggested Revisions
- 0 Tier 3 Future Considerations

#### Tier 1 Recommendation for Charge 2.b

[underlined: SAB Recommendation (1 of 4 Tier 1 for Charge 2.b):] The panel recommends EPA present the logic and sequence of inclusion of individual studies in the text, tables, and figures.

[underlined: EPA Response:] All PECO-relevant studies are displayed in literature tag-trees, which also shows the separation of studies considered medium/high confidence versus low confidence. The medium or high confidence studies were prioritized for discussion and presentation in the text, tables, and figures of the assessment. EPA has confirmed all medium/high confidence studies are cited in the text and included in the study evaluation heatmaps in the main assessment (low confidence study heatmaps can be found in Section B.4). EPA has added text outlining the criteria for including studies in figures (see Section 1.6.3). For example, a forest plot was not created if the plot would only display a single estimate. At least two estimates that were generally comparable were required in order to create a plot. EPA has confirmed that every medium/high confidence PECO-relevant study that meets specified figure plotting criteria is included in a forest plot, as discussed in Section 1.6.3.

[underlined: SAB Recommendation (2 of 4 Tier 1 for Charge 2.b):] The assessment needs to clearly distinguish between studies from highly exposed populations and lower exposures.

[underlined: EPA Response:] Not all studies clearly report external exposure levels in environmental media for the populations under investigation. Therefore, EPA is unable to consistently report this information across studies included in the assessment. Where possible, EPA has added context regarding exposure in conjunction with the narrative description of results. To further help address this comment, EPA has provided additional text and Figure 1-1 from Schwarzenbach et al. (2010) in Section 1.5.1. to illustrate general expected exposure levels across the world so that users can have this context as they read the assessment. Building from this, the HAWC forest plots now present the country where the study was conducted. Finally, EPA also presents new, targeted supplemental data pivots (see Section B.5). These pivots are comprised of studies considered in hazard identification that represent maximum arsenic drinking water exposures of ≤ 100 µg/L) (See Section B.5).

[underlined: SAB Recommendation (3 of 4 Tier 1 for Charge 2.b):] The panel recommends placing the number of available studies under the outcome on the x-axis instead of using a cut point of <25 or >25 datasets (see Figure 4-1). The panel also recommends denoting the studies selected for dose-response analyses.

[underlined: EPA Response:] Figure 4-1 has now been revised to include the number of studies under the outcome on the x-axis. Since the relative risk to background exposure (RRB) analysis was a screening analysis not all datasets from studies used in the meta-analyses were included in the RRB analysis. Therefore, denoting the studies/datasets that were selected for meta-analysis in Figure 4-1 would not be a complete representation. However, all datasets used in the meta-analyses are listed in Section 4.3.

[underlined: SAB Recommendation (4 of 4 Tier 1 for Charge 2.b):] The assessment needs clarification on the key confounders, covariates, and risk modifiers and how these were incorporated into the assessment and synthesis.

[underlined: EPA Response:] Section 1.6.2. contains a discussion of some of the common confounders considered for each of the four outcomes described in Evidence Synthesis, e.g., smoking, sex, age, BMI, SES. Section 1.6.2. also contains a discussion of the study evaluation process that considers confounding. Additional details on the study evaluation process can be found in the Protocol (see Section 3.9).

#### Tier 2 Suggestions for Charge 2.b

[underlined: SAB Suggestion (1 of 5 Tier 2 for Charge 2.b):] Arsenic speciation information should be included for studies using urinary arsenic, if available. If arsenic was not speciated or does not include measurement of arsenobetaine, the use of total urinary arsenic is an adequate biomarker of iAs exposure if seafood intake is rare in the population.

[underlined: EPA Response:] Measurement and analysis of urinary arsenic species can be used as indicators for the metabolism of inorganic arsenic. Information on arsenic speciation was included when available. More specifically, if a study investigated and reported information on arsenic metabolites, speciation was noted in the assessment text. Most iAs studies considered for dose-response used urinary biomarkers as the exposure metric either conducted their studies in populations with low seafood intake or reported that arsenobetaine (which is obtained solely through the ingestion of seafood) made up a very low percentage (<5%) of the total urinary arsenic concentration. Therefore, for these studies, confounding of total urinary arsenic concentrations by non-toxic organo-arsenic species is not considered a major complication. As discussed in Section 1.6.2, some studies adjusted for seafood consumption, such as through speciating urinary arsenic and excluding arsenobetaine. Others confirmed low seafood consumption in the study population, or asked participants not to consume seafood prior to study inclusion. Other studies did not address potential confounding by organic arsenic by seafood intake. Consideration of speciation and/or seafood intake (in design or analysis) was considered during study evaluation and documented in HAWC (e.g., restricted analyses to those with low or no seafood intake; had participants refrain from seafood consumption prior to biomarker collection; adjusted for seafood consumption measured from food frequency questionnaire; used measurement of arsenobetaine in analyses). However, lack of speciation was not on its own considered a limitation that would preclude consideration of the study for hazard characterization (when applicable) or dose-response analysis.

With regard to how this issue potentially impacted dose-response analysis, a bladder cancer sensitivity analysis regarding excluding urine studies that did not account for seafood consumption or arsenobetaine urine concentrations indicated that the pooled logistic slope parameter would increase if these studies were excluded. Thus, calculated lifetime extra risks would increase if these studies were excluded. No sensitivity analysis regarding urine studies and seafood consumption was possible for the birth weight meta-analysis given only three studies were used in the meta-analysis). However, given the single-study Kile et al. (2016) analysis was ultimately selected as the basis of the birth weight candidate value. The lack of sensitivity analysis for birth weight meta-analysis is not seen as a critical issue.

[underlined: SAB Suggestion (2 of 5 Tier 2 for Charge 2.b):] Pregnancy and early childhood studies described in the text should also be included in the forest plots.

[underlined: EPA Response:] EPA has confirmed that every study that meets criteria for inclusion in a forest plot, such as needing to include a ratio measure or difference measure, and being a sub-outcome of n > 1, is now included in a forest plot. For more details on criteria for inclusion in a forest plot, please see Section 1.6.3.

[underlined: SAB Suggestion (3 of 5 Tier 2 for Charge 2.b):] EPA should review the assignment of the study design for cross-sectional studies.

[underlined: EPA Response:] EPA has reviewed this section to make any necessary clarifications regarding study design. For example, EPA has clarified that Bulka et al. (2022) is a cross-sectional study and not a cohort study.

[underlined: SAB Suggestion (4 of 5 Tier 2 for Charge 2.b):] Although there was clarity and consistency for studies that met high or medium confidence criteria, EPA should provide more details about the specific metrics used to discount studies from consideration.

[underlined: EPA Response:] Information on this process is provided in Section 1.6.2. of the assessment as well as in the protocol. In addition, the assessment has been revised to clarify the study selection process. PECO criteria were used to identify human evidence that addresses the specific aims of the assessment and to focus the literature screening, including study inclusion/exclusion (See Section 1.6.1 and Table 1-2). As discussed in the assessment and protocol, animal and mechanistic data are considered supplemental material and not tracked as PECO relevant (other categories of “potentially relevant supplemental material” are also described in Section 1.6.1). Human studies meeting PECO criteria were subject to risk of bias (RoB) evaluations to determine further eligibility for consideration in the assessment. Given the abundance of medium and high confidence studies, low confidence studies were not included in the evidence synthesis analysis. HAWC literature trees have been updated to better capture this study flow. As part of the study selection process for inclusion in dose-response, various study design features and consideration of control for smoking was considered and new figures have been added to the assessment to document this process. With respect to smoking, whether a study controlled or accounted for smoking was a critical exclusion criterion, and studies that did not sufficiently consider smoking (through study design or analysis) were excluded from dose-response. The study selection for all meta-analyses is described in Section 4.3.1, “Identification of Studies and Data for Bladder Cancer, Lung Cancer, Diseases of the Circulatory System, and Diabetes dose-response meta-analyses.”

[underlined: SAB Suggestion (5 of 5 Tier 2 for Charge 2.b):] For the non-cancer health outcomes discussed in the assessment, EPA should comment on the interplay across individual health outcomes as it relates to risk modification.

[underlined: EPA Response:] A discussion of potential risk modification or mediation from interrelated health outcomes has been added to “Impact of Other Factors” in Section 1.6.2.

#### Tier 3 Future Considerations for Charge 2.b

The reviewers had no Tier 3 future considerations.

### F.1.4 Public Comments on Systematic Review and Documentation

[underlined: Public Comment:] Two public commenters (Electric Power Research Institute and Superfund Settlement Project and RCRA Corrective Action Project) noted a lack of clarity regarding the literature search documentation and history of the literature search strategy and keywords used for each literature search update, including a discrepancy in the literature search dates in the assessment text and Table B-1 in Appendix B of the Protocol. Commenters were not clear on whether or not the same literature search strategy was used for all literature searches, including the search conducted after prioritization of health outcomes.

[underlined: EPA Response:] EPA has clarified the literature search documentation and history by adding dates of the literature search updates (January 2019, August 2022, and a targeted search for neurodevelopment studies in August 2024) to Table B-1 in Appendix B of the Protocol so that the dates in the assessment are now consistent with Table B-1. As shown in Table B-1, the literature search strategy and keywords used for each search was the same.

[underlined: Public Comment:] One commenter (Electric Power Research Institute) noted that “Studies published after 2019 were not considered as part of the hazard assessment for DCS or diabetes, and the rationale provided was that the hazard judgment (i.e., “evidence demonstrates”) had been established previously and the new literature would not inform the hazard judgment (see Figures 3-3, 3-21). It is not clear if the hazard for diabetes (or DCS) was established by the USEPA in 2019 without a peer-review of the evidence, and whether the USEPA relied solely on the NRC report (NRC, 2013). NRC (2013) provided a recommendation to prioritize diabetes as an endpoint to assess but did not itself conclude that diabetes was causally associated with iAs.

[underlined: EPA Response:] As described in Section 3.4 of the Updated Problem Formulation and Protocol and Section 1.6.1. of the assessment, the characterization of newly identified studies from the 2022 literature search update focused on EPA’s judgment of whether studies would have a material impact on the conclusions (i.e., identified hazards or toxicity values). Based on the studies identified up to 2019, EPA conducted evidence synthesis analyses for DCS and diabetes and determined the evidence was robust for both outcomes. These preliminary conclusions were presented in the 2019 protocol which underwent review by (NASEM, 2019). The NASEM panel concurred with these conclusions. In addition, detailed evidence synthesis analysis for both DCS and diabetes were presented in the draft IRIS Toxicological Review of Inorganic Arsenic released in October 2023 for public comment and SAB review. The SAB concurred with the hazard judgements.

DCS and diabetes studies identified in the most recent literature search update (August 2022) did not undergo study evaluation because EPA already characterized the strength of the evidence base for these health outcomes to be robust (based on studies identified up to 2019) and EPA determined that new studies would not impact existing hazard conclusion. However, these studies were considered for dose-response utility and evaluated against criteria of particular importance for EPA’s dose-response meta-analysis approach.

[underlined: Public Comment:] Two public commenters (Electric Power Research Institute and Superfund Settlement Project and RCRA Corrective Action Project) noted that it is unclear if data extraction was performed on studies identified in the most recent literature search update conducted in 2022. Commenters referred to Figure 2.2 that shows 169 studies from 2022 literature search update were considered relevant after full text screening, but these studies were not evaluated. Commenters are unclear on whether any of these 169 studies were considered “informative” and included in data extraction. “However, a search of the study quality and risk of bias spreadsheets accessed through a link provided in the Toxicological Review (USEPA 2023a) indicated no studies published from 2019 to 2022 were considered for quality assessment.” Two commenters (USA Rice and the Pesticide Policy Coalition) stated that “study selection does not reflect the current body of scientific evidence. Few, if any, studies published after the adoption of the protocol in 2019 are included, ignoring four years of recent arsenic studies.”

[underlined: EPA Response:] As described in Section 1.6.1. the characterization of newly identified studies from the 2022 literature search update focused on whether studies would impact hazard conclusions or dose-response analyses. DCS and diabetes studies did not undergo study evaluation because EPA already characterized the strength of the evidence base for these outcomes to be robust (based on studies identified up to 2019) and new studies would not impact the hazard conclusion. EPA characterized the strength of the evidence base to be moderate for fetal, newborn, and infant health outcomes and neurodevelopmental effects (based on studies identified up to 2019) and studies identified in the 2022 update underwent risk of bias evaluation to determine if new studies would change the hazard conclusion and/or impact dose-response analyses. These study evaluations can be found in HAWC, and the results of these studies can be found in the narrative text and associated forest plots.

[underlined: Public Comment:] Two public commenters (Electric Power Research Institute and Superfund Settlement Project and RCRA Corrective Action Project) noted that “the OHAT approach proposed in 2013 has been updated since the original arsenic protocol was completed. In addition, since the 2013 arsenic protocol, USEPA’s IRIS and TSCA programs have developed protocols for determining risk of bias and data quality. Therefore, over a decade of consideration and updates to the original OHAT (NTP, 2013) risk of bias evaluation process has been applied and new approaches in evaluating study quality and risk of bias have been developed and should be applied in the USEPA (2023a, 2023b) assessment.”

[underlined: EPA Response:] Like other research tools and methodologies, specific study evaluation protocols (e, g., IRIS, OHAT approach) are often refined over time to improve clarity and ease of using the tool based on user feedback or advances in the field. Please note that TSCA does not have a finalized data quality evaluation framework. Both IRIS and OHAT approaches are state of the art domain-based tools probing the same underlying considerations (e.g., confounding, exposure assessment, etc.) (U.S. EPA, 2022). Thus, refinements in the OHAT study evaluation approach over time are relatively minor and do not impact individual or overall domain judgements. Moreover, the study evaluation approach used in the IRIS assessment was included in the protocol, which underwent NASEM peer review in 2019 (NASEM, 2019). Thus, a redo of the studies is not warranted.

[underlined: Public Comment:] One public commenter (Rosalind Schoof) commented that EPA failed to reassess the inhalation unit risk factor for arsenic that was derived in 1984. The commenter provided references on inhalation studies and pointed to agencies that derived inhalation unit risks (e.g., California Air Resources Board (CARB), World Health Organization (WHO), the Dutch Expert Committee on Occupational Safety (DECOS), and Texas Commission on Environmental Quality (TCEQ).

[underlined: EPA Response:] Since oral exposure is the primary route of exposure for the general population, developing oral toxicity values was prioritized and inhalation exposure to inorganic arsenic was not re-evaluated (discussed in Section 1.5.1. and PECO Table 1-2). The inhalation unit risk that was developed by IRIS in 1984 was not reassessed. In addition, inhalation studies are mainly occupational studies, and the bulk of the new epidemiological studies concern oral exposure.

[underlined: Public Comment:] One public commenter (National Council for Air and Stream Improvement, Inc.) noted areas that need more details, including criteria used to make causal conclusions, exclusion criteria, and risk of bias criteria, citing the Assessment Development Plan. They further noted that the draft OHAT framework is not provided in the assessment and that “very few questions were selected for the protocol without clear explanation of why the limited question set was selected.”

[underlined: EPA Response:] The original Assessment Development Plan was released in 2014 as part of the Preliminary Assessment Materials. The scope, problem formulation considerations, and methods were updated in a Protocol that was released and reviewed by NASEM in 2019 (NASEM, 2019). The Populations, Exposures, Comparators, and Outcomes (PECO) criteria and OHAT approach and questions used are included in Section 3.2 and Appendix C of the Updated Problem Formulation and Protocol for the Inorganic Arsenic IRIS Assessment, respectively. PECO criteria are also included in Table 1-2 of the assessment. Section 3.10, Evidence Synthesis of Epidemiological Evidence, of the Protocol discusses criteria used to make causal conclusions.

[underlined: Public Comment:] One public commenter (National Council for Air and Stream Improvement, Inc.) noted that a systematic review regarding neurological effects in children (Tsuji et al., 2015) came to different conclusions than the IRIS draft assessment. “While it is recognized that additional outcomes were evaluated in the draft (for which the authors of the draft concluded higher confidence in the evidence base than the pregnancy/birth outcome), it is the fact that different reviewers evaluating a similar evidence base and coming to different conclusions that is concerning. It speaks to the need for the review to be conducted in a manner that is independently reproducible by following a protocol with clear and detailed criteria for each step of the review. In the absence of this, the conclusions of the current draft review may not represent the highest quality of science available for policy decision making.”

[underlined: EPA Response:] The publication noted above is a review article from 2015 and does not include all of the studies considered in the IRIS assessment., i.e., the IRIS assessment evaluation of neurodevelopment included studies up to 2024 (51 studies). In addition, EPA conducts an independent analysis of the available primary data articles in accordance with EPA guidelines and the IRIS handbook, so the stance of EPA on the impact and utility of the papers to inform assessment conclusions can differ from the views and conclusions expressed by other review authors. Please see the Updated Problem Formulation and Protocol for the Inorganic Arsenic IRIS Assessment, which describes systematic review and dose-response methods that were used to complete the draft assessment. The document underwent peer review by the NASEM in 2019 (NASEM, 2019).

[underlined: Public Comment:] One public commenter (Superfund Settlement Project and RCRA Corrective Action Project) found “The documentation and methods used to identify studies and data for inclusion in Bayesian meta-regression dose-response analyses are lacking in transparency. While the methods for study and data selection are presented in the Systematic Review Protocol, it is impossible to follow the decision process through the Systematic Review (USEPA 2023a), Systematic Review Supplemental Data (USEPA 2023b), and the BMD data files.”

[underlined: EPA Response:] Section 4.3.1, “Identification of Studies and Data for Bladder Cancer, Lung Cancer, Diseases of the Circulatory System, and Diabetes dose-response meta-analyses,” has been updated and clarifications added to improve transparency.

[underlined: Public Comment:] One public commenter (Superfund Settlement Project and RCRA Corrective Action Project) noted that “not all of the studies that are presented in Figures 3-22 and 3-23 considered medium- or high-confidence studies are presented in the file iAs_study_selection_fordose_response_Jan2021.xlsx. Therefore, it seems that not all studies that underwent risk of bias evaluation and received a medium- or high-confidence rating were considered for qualitative analysis. Overall, a transparent method for mapping each study’s progress through risk of bias and confidence evaluations to consideration and decisions regarding inclusion in the qualitative evaluations is needed.”

[underlined: EPA Response:] It is not clear from the public comment whether the focus is on inclusion of studies in qualitative evidence synthesis for reaching hazard conclusions, for quantitative dose-response, or both. The assessment has been revised to clarify the processes for study inclusion for both hazard characterization and dose-response, see responses above to “SAB Recommendation (1 of 3 Tier 1 for Charge 2.a)” “SAB Recommendation (2 of 3 Tier 1 for Charge 2.a),” and “SAB Suggestion (5 of 6 Tier 2 for Charge 2.b).”

[underlined: Public Comment:] One public commenter (Dr. Paolo Boffetta) noted inconsistencies and lack of transparency in the studies selected for dose-response and evidence synthesis for diabetes. “The study by D’Ippoliti et al. (2015) was included in the dose-response for lung cancer, but not in the same analysis for bladder cancer, with no clear explanation about it; notably, in this study there was a statistically significant positive dose-response for lung cancer, but not for bladder cancer. Studies on diabetes based on drinking water published in 2018 were excluded (Marie et al., 2018; Chafe et al., 2018; Castriota et al., 2018), whereas some studies based on urine markers were included [e.g., (Xiao et al., 2018; Velmurugan et al., 2018; Grau-Perez et al., 2017)]. In general, the exclusion of studies published after 2017 (or 2018) is not justified.”

[underlined: EPA Response:] The study selection for all meta-analyses is described in Section 4.3.1, “Identification of Studies and Data for Bladder Cancer, Lung Cancer, Diseases of the Circulatory System, and Diabetes dose-response meta-analyses.” EPA has revised its study selection workflow for identifying studies suitable for dose-response analysis. As part of that study selection process, whether a study controlled or accounted for smoking was a critical exclusion criterion, and studies that did not sufficiently consider smoking (through study design or analysis) were excluded from dose-response. After consideration of how D’Ippoliti et al. (2015) adjusted for smoking on the municipal level (rather than on an individual-by-individual basis), EPA agrees that D’Ippoliti et al. (2015) should be removed from all dose-response meta-analyses. All of the studies listed by the commenter were considered, but only Grau-Perez et al. (2017) was included in the diabetes meta-analysis.

[underlined: Public Comment:] One public commenter (Dr. Paolo Boffetta) said EPA does not sufficiently consider residual confounding. “Potential confounding by creatinine in studies based on urine markers is ignored. Creatinine is the product of the breakdown of creatine phosphate from metabolism of muscle and protein-rich tissues. It is excreted in urine at a constant rate, depending mainly on muscle mass. Under normal circumstances, urine creatinine is a valid indicator or urine concentration, hence its use to adjust results of other urinary biomarkers to account for concentration. However, decrease in urinary creatinine level may occur, especially in two circumstances: (i) reduced kidney function, which may be due to acute and chronic kidney disease, as well as to diabetes, and (ii) reduced muscle mass (sarcopenia), which may be due to muscle wasting conditions such as cancer, as well as to malnutrition and reduced physical activity. The use by EPA of creatinine-adjusted results from studies on urinary arsenic level and chronic conditions which may affect creatinine level, such as diabetes and cancer, likely resulted in an overestimate of the association.”

[underlined: EPA Response:] EPA does not believe an assumption of normal creatinine levels would result in an overestimation of risk. It would result in an underestimation of the association of iAs levels and risk. Kuo et al. (2022) recently concluded that urine creatine correction may be a better method to correct for urine dilution when evaluating the effect of arsenic exposure for cardiovascular or metabolic outcomes, which is also consistent with a review by Hsieh et al. (2019). The SAB also stated that “urinary arsenic corrected by urinary creatinine is an adequate method to correct spot urine samples for urine dilution (SAB, 2024).”

## F.2 CHARGE QUESTION 3–NONCANCER HAZARD IDENTIFICATION

3) For each health effect prioritized for hazard identification in the assessment based on the protocol for inorganic arsenic and outlined below, please comment on whether the available epidemiological data (the primary focus of these analyses based on recommendations from the NASEM) have been clearly and appropriately synthesized to describe the strengths and limitations. Please also comment on whether the weight-of-evidence decisions for hazard identification are scientifically justified and clearly described, and appropriately consider health effects in susceptible subpopulations or lifestages (e.g., children) to the extent possible, given the available data.
  a) For diseases of the circulatory system, the Toxicological Review concludes the currently available evidence demonstrates that inorganic arsenic causes cardiovascular effects in humans given sufficient exposure conditions. This conclusion is based on studies of humans that assessed exposure levels of <10 µg/L to 930 µg/L showing increased ischemic heart disease and hypertension, as well as related cardiovascular disease endpoints of atherosclerosis and repolarization abnormalities (e.g., QT prolongation).
  b) For diabetes, the Toxicological Review concludes the currently available evidence demonstrates that inorganic arsenic causes diabetes in humans given sufficient exposure conditions. This conclusion is based on studies of humans that assessed exposure levels of <150 µg/L to >150 µg/L showing increased incidence of diabetes mellitus (Type 1 and Type 2 diabetes).
  c) For pregnancy and birth outcomes, the Toxicological Review concludes the currently available evidence indicates that inorganic arsenic likely causes pregnancy and birth effects in humans given sufficient exposure conditions. This moderate epidemiology evidence generally supports a weaker hazard judgment, although the specific judgment reached is more heavily influenced by other lines of evidence than when there is robust epidemiological evidence. Although there is notable uncertainty in this judgment without reviewing the other lines of evidence (out of scope for this assessment), it is reasonable to judge that the available evidence indicates that pregnancy and birth effects are likely caused by iAs exposure, given sufficient exposure conditions. This conclusion is based on studies of humans that assessed exposure levels of <100 µg/L to >100 µg/L showing decreased fetal and post-natal growth or length of gestation.
  d) For neurodevelopmental effects, the Toxicological Review concludes the currently available evidence indicates that inorganic arsenic likely causes neurodevelopmental effects in humans given sufficient exposure conditions. This moderate epidemiology evidence generally supports a weaker hazard judgment, although the specific judgment reached is more heavily influenced by other lines of evidence than when there is robust epidemiological evidence. Although there is notable uncertainty in this judgment without reviewing the other lines of evidence (out of scope for this assessment), it is reasonable to judge that the available evidence indicates that neurodevelopmental effects are likely caused by iAs exposure, given sufficient exposure conditions. This conclusion is based on studies of humans that assessed exposure levels of <100 µg/L showing cognitive and behavioral deficits in children and adolescents.

### F.2.1 SAB Peer Review Comments on Diseases of the Circulatory System (Charge Question 3.a)

The report states, “A major effort has been expended to synthesize the available epidemiological evidence for iAs and diseases of the circulatory system. Overall, the effort is comprehensive and detailed, allowing one to obtain a complete picture that includes both clinical and subclinical outcomes. The process of how the studies were identified, evaluated, and how they were considered depending on the level of confidence is clearly explained. Given the number of studies identified for the hazard identification phase already in the 2019 search, it makes sense that the additional studies identified in the 2022 search were only included for the dose-response meta-analysis and not additionally included for the hazard identification phase, since the inclusion of additional studies was not going to be influential. Overall, the weight-of-evidence decisions for hazard identification are scientifically justified, clearly described, and appropriately consider health effects in susceptible subpopulations (e.g., effect modification by sex for QT interval prolongation and ischemic heart disease; by methylation capacity for atherosclerosis). The most significant concern regarding the evidence for the cardiovascular outcomes, is that while in the screening and descriptive process it is appropriate to include the different clinical and subclinical outcomes, for the meta-analysis the SAB recommends that IRIS focuses on ischemic heart disease as the key endpoint.” The report elaborates on this concern (see full report for details) and provides several related comments, noting that, “Selecting either IHD mortality (fatal events only) or IHD incidence (both fatal and non-fatal events) would be appropriate for the dose-response analysis.”

The SAB panel’s tiered comments on Charge Question 3.a were:

- 1 Tier 1 Recommended Revisions
- 1 Tier 2 Suggested Revisions
- 0 Tier 3 Future Considerations

#### Tier 1 Recommendations for Charge 3.a

[underlined: SAB Recommendation (1 of 1 Tier 1 for Charge 3.a):] The assessment should focus on ischemic heart disease as the main endpoint. For the dose-response analysis, EPA should conduct analyses of both IHD mortality (fatal events only) and IHD incidence (both fatal and non-fatal events).

[underlined: EPA Response:] The assessment has been revised to include ischemic heart disease (IHD) as a key endpoint under the Diseases of the Circulatory System (DCS) section (see Section 3.2.1). The IHD subsection also now has its own branch in the literature tag-tree, IHD-exclusive figures to include IHD incidence and mortality, and IHD-specific assessment text. The revised assessment now only considers IHD incidence (both fatal and non-fatal events) for dose response analyses. The IHD mortality endpoint was not modeled using the hierarchical Bayesian meta-analysis approach because only two studies were available (and three studies was considered the minimum to support a meta-analysis).

#### Tier 2 Suggestions for Charge 3.a

[underlined: SAB Recommendation (1 of 1 Tier 2 for Charge 3.a):] Remove Li et al. (2007) from Figure 3-13-a.

[underlined: EPA Response:] Li et al. (2007) has been removed from Figure 3-13-a in the revised assessment.

#### Tier 3 Future Considerations for Charge 3.a

The reviewers had no Tier 3 future considerations.

### F.2.2 Public Comments on Diseases of the Circulatory System

[underlined: Public Comment:] One commenter (Superfund Settlement Project and RCRA Corrective Action Project said, “it would be helpful to lay out the proposed biological pathway by which inorganic arsenic exposure causes cardiovascular effects in humans,” noting atherosclerosis, hypertension, ischemic heart disease, stroke, and QT prolongation. “A clearer evaluation of the mechanistic data and the pathway from iAs exposure to clinical effects and population-level effects could support (or be used to argue against) the evidence synthesis.”

[underlined: EPA Response:] Appendix A of the protocol describes the MOA analyses conducted by EPA to characterize biological pathways associated with arsenic exposure, focusing on pathways that may be common to multiple adverse health effects versus tissue specific descriptions. Many of these MOAs are pertinent to cardiovascular cellular response and function. Section 3.2.1 of the revised assessment includes additional discussion of mechanistic studies that support the biological plausibility of arsenic effects on the circulatory system, in particular citing multiple in experimental animal models that report that arsenic exposure stimulates dysregulation of angiogenesis and atherosclerosis. See also response to “SAB Recommendation (3 of 3 Tier 1 for Charge 2.a”).

[underlined: Public Comment:] Two commenters (Electric Power Research Institute and Superfund Settlement Project and RCRA Corrective Action Project) referred to Figure 3-3, literature tree of epidemiological studies assessing DCS, and noted that it is not clear why the post-2019 studies were not considered as part of the hazard assessment. Further, “the USEPA (2023a) states that none of the 48 studies post-2019 were relevant for meta-regression. The 48 studies identified post-2019 represent 28% of the 171 studies, a large proportion. Did none of the post-2019 studies have information that pertained to low exposure? There may still be relevant qualitative information in these studies even if none of them were relevant for meta-regression analysis. Some examples of the 48 studies that were excluded and may be relevant (based on a review of abstracts include): cardiovascular disease mortality (Xu et al., 2020; Nigra et al., 2021; Kuo et al., 2022; Al-Forkan et al., 2021); among others) and hypertension (Liu et al., 2022b; Kaufman et al., 2021; Desai et al., 2021).”

[underlined: EPA Response:] This topic is discussed in Section 1.6.1 of the assessment. See also response to “SAB Recommendation (2 of 3 Tier 1 for Charge 2.a).” The characterization of newly identified studies from the 2022 literature search update focused on EPA’s judgment of whether studies would have a material impact on the conclusions (i.e., identified hazards or toxicity values) in the external review draft (see Table B-17 in Section B.3). DCS studies identified in the most recent literature search update (August 2022) did not undergo study evaluation because EPA already characterized the strength of the evidence base for these health outcomes to be robust (based on studies identified up to 2019) and EPA determined that these new studies would not impact the draft hazard conclusion. However, as discussed in Section 4.3, these studies were considered for dose-response utility and evaluated against criteria of particular importance for EPA’s dose-response meta-analysis approach (see the iAs Protocol, Section 5.2.1). Only one study, Nigra et a. (2021), was deemed appropriate for Bayesian meta-analysis dose-response given the study selection workflow described in Section 4.3. However, this study was an IHD fatality study, and this endpoint was ultimately not included in the endpoints modeled in the assessment. Therefore, of the DCS studies identified in the August 2022 literature search update, none were included in the Bayesian meta-analysis dose-response.

[underlined: Public Comment:] With regards to CVD/IHD incidence, one commenter (Superfund Settlement Project and RCRA Corrective Action Project) noted that “there was no information in HAWC to justify the overall ratings of “probably low risk of bias.” Importantly, what are the most potential sources of bias in these studies? USEPA (2023a) should provide the most important sources of bias in the text. Which confounders were considered, and which confounders were adjusted for in the analyses? Which studies are low-exposure studies and which studies are high-exposure studies?”

[underlined: EPA Response:] Newly added Section 1.6.2 contains a discussion of some of the core confounders considered for each of the four outcomes described in Evidence Synthesis, including DCS. Section 1.6.2 also contains a discussion of the study evaluation process with additional details provided in the Protocol (see Section 3.9). The phrase “probably low risk of bias” is used to summarize an individual domain judgement (e.g., confounding or detection domain) and is not used to describe an overall study rating. The rationales for individual domain level judgments are available in the interactive study evaluations presented in HAWC. For studies judged as overall medium or high confidence studies, the rationales for any “probably low risk of bias” domain level judgments can be accessed through HAWC study evaluation heatmaps presented in the main assessment. For studies judged as overall low confidence, the study heatmaps can be found in Section B.4.

In terms of distinguishing between low and high exposure levels, not all studies clearly reported external exposure levels in environmental media for the populations under investigation. Therefore, EPA was unable to consistently report this across the assessment. Instead, to address this comment, EPA has provided a map in Section 1.5.1 to illustrate general expected groundwater exposure levels globally to help contextualize by geographic region for users as they read the assessment. See also response to “SAB Recommendation (2 of 3 Tier 1 for Charge 2.b).”

[underlined: Public Comment:] One commenter (Superfund Settlement Project and RCRA Corrective Action Project) pointed to one of NRC’s (2013) recommendations for cardiovascular disease. “In evaluating the causal relationship between arsenic exposure and cardiovascular diseases, however, USEPA should address potential uncertainties resulting from differences between the study population and the general population. Animal data and data that reveal potential modes of action demonstrate sensitivity of the cardiovascular system to arsenic exposures relevant to humans and support identification of modes of action. That can be useful for supporting causality in the epidemiologic studies, help to identify sensitive populations, and inform the dose–response analysis.”

[underlined: EPA Response:] With respect to mode of action, Appendix A of the protocol describes the MOA analyses conducted by EPA to characterize biological pathways associated with arsenic exposure, focusing on pathways that may be common to multiple adverse health effects versus tissue specific descriptions. In addition, Section 3.2.1 of the assessment has been revised to include additional discussion of mechanistic studies that support the biological plausibility of arsenic effects on the circulatory system, citing multiple arsenic-induced atherosclerosis and arsenic-induced dysregulation of angiogenesis studies in experimental animals. See also response to “SAB Recommendation (3 of 3 Tier 1 for Charge 2.a”). With respect to generalizability of results, studies included in the hazard evaluation and dose response analysis were conducted in populations across different countries and exposure levels with largely consistent findings, which reduces concerns that findings are specific to one study population.

[underlined: Public Comment:] One commenter (Superfund Settlement Project and RCRA Corrective Action Project) stated that the “key finding for cardiovascular disease/IHD incidence and mortality, reported in the evidence profile table (see Table 3-2), relates to low exposure studies….it would be helpful to cite the large prospective cohort studies in the table. These studies cannot be easily determined based on the information presented in the forest plots and study evaluation ratings (risk of bias summary figures).”

[underlined: EPA Response:] Forest plots are grouped by study design, with the exception that cohort and case-control studies are plotted together for efficiency. EPA has added a descriptive column to identify study design for the forest plots that present cohort and case-control studies together. To help identify the large prospective cohort studies, EPA has ensured that each forest plot contains the column ‘N,’ representing the total number of participants included in a study’s analysis, to facilitate finding information about study size.

[underlined: Public Comment:] One commenter (Superfund Settlement Project and RCRA Corrective Action Project noted that the factors in Table 3-2 do not appear to increase or decrease certainty. “The USEPA states “most studies are medium or high confidence” as a factor that increases the certainty of the key finding. Is this referring to the “large prospective studies” in the key finding? Or is it referring to the entire body of human studies? The USEPA also reported “Consistency–across study types, including cross-sectional, and ecological “natural experiments;” across populations including U.S., Bangladesh, China, Taiwan, and Mexico” increases certainty in the key finding. The results are not presented according to study type in the forest plots. The forest plots should group the studies by study design. In addition, “Consistency” in the direction or magnitude of the overall risk estimates cannot easily be evaluated because it is not easy to identify which studies (and how many) are cross-sectional studies, which studies (and how many) are cohort studies, which studies (and how many) are case-control studies, and which studies are natural experiments.

[underlined: EPA Response:] The US EPA statement that “most studies are medium or high confidence” refers to increased certainty in conclusions for each of the sub-outcomes in that table. This is an across the body of studies judgement. Because the data summarized for each outcome in this table are based on medium and high confidence studies, there is more certainty in the key findings (compared to if the results were from low confidence studies). With regard to the suggestion to plot studies by study design in the forest plot, EPA notes that forest plots are already grouped by study design, with the exception that cohort and case-control studies are plotted together for efficiency. Study type is noted in each forest plot. Additionally, every study that meets figure plotting criteria (see Section 1.6.3) is now plotted to facilitate observing patterns across studies. Standardized descriptions of the figures throughout the assessment and how they are organized can be found in the newly added section 1.6.3. See also response to “SAB Recommendation (1 of 3 Tier 1 for Charge 2.b).”

[underlined: Public Comment:] One public commenter (Superfund Settlement Project and RCRA Corrective Action Project) noted “The USEPA stated that a “Large or concerning magnitude of effect–large odds ratios in some studies” increased the certainty. Which studies reported large odds ratios? What is the magnitude of a “large” odds ratio? Are the odds ratios of similar magnitude to other estimates of relative risk? Odds ratios may be overestimated when the disease is not a rare disease.”

[underlined: EPA Response:] There is no bright line for what is considered a “large” odds ratio. This decision is based on expert judgement in the context of the specific exposure and outcome relationships being evaluated. This includes, for example, ORs of >4, >5, and >6 as presented in forest plots for IHD in Section 3.2.1 (Wade et al., 2009; Jin et al., 2016; Chen et al., 1996).

[underlined: Public Comment:] One public commenter (Superfund Settlement Project and RCRA Corrective Action Project) noted “The USEPA reported that “Dose-response gradient–observed in many studies” increased the certainty of the evidence in the key finding. Again, is this related specifically to the key finding, i.e., “large prospective cohort studies” and “relatively low exposures to iAs in drinking water?” Which studies identified a dose-response gradient and at what concentrations? The forest plots include studies of different measurement units (e.g., ppb, μg/mL) and different exposure metrics (cumulative exposure, average exposure). This makes the results difficult to compare. Which studies did not identify a dose-response gradient and what were the differences between the studies that did and the studies that did not? (For example, did certain studies adjust for different confounders)? The ORD Handbook suggests grouping studies by study design. There are two issues related to dose-response gradients for the noncancer hazard identification: 1) the biological gradient should be considered as one of modified Hill considerations for the hazard identification (as a factor that increases the certainty of the evidence), and 2) can the existing epidemiological data be used for dose-response for purposes of the risk assessment? It is reasonable that the biologic gradient can be demonstrated in the hazard identification (issue 1); however, there must still be an assessment of whether the existing epidemiological data can be used for purposes of the dose-response assessment.”

[underlined: EPA Response:] With regard to figures, as stated in Section 1.6.3, they “include studies that vary across different dimensions, such as the use different effect estimates, different exposure assessment techniques as described in the column labeled “Exposure metric,” the use of different reference and exposure groups, and different increments of arsenic for associated regression coefficients. Thus, quantitative comparisons of the magnitude of the associations between studies is not appropriate. The intent of the figures is to facilitate analyses of patterns of associations across studies.” To increase clarity on dose-response gradient, each hazard section now includes a list of studies that identified a pattern of a dose-response relationship. These patterns can also be observed in the forest plots within the assessment. While many studies did identify suggestive dose-response gradients, not every study did. Overall, most studies did observe a dose-response gradient. Some variation in the pattern of results is expected across any body of evidence. When dose-response gradient is detected in many studies, this is reflected in the evidence profile tables as a factor that increases certainty in conclusions drawn from evaluating a body of studies assessing the same outcome.

[underlined: Public Comment:] One public commenter (Superfund Settlement Project and RCRA Corrective Action Project) stated that “with respect to “Coherence with findings for related endpoints” as a factor that increases the certainty, hypertension is discussed as its own endpoint in the same table (see Table 3-2 of USEPA, 2023a). The evidence synthesis judgment for hypertension was described as “robust;” however, robust evidence does not seem consistent with the key finding for hypertension: “Some, but not all, well-designed cohort studies report positive associations. Results are sensitive to the choice of exposure metric.”

[underlined: EPA Response:] The hypertension judgment determination is described in more detail in Section 3.2.1 of the assessment. Briefly, this judgment was determined due to exposure-dependent associations of arsenic exposure (drinking water concentrations, cumulative exposure and biomarkers or arsenic or its metabolites in urine) with prevalent hypertension across studies; a large magnitude of effect observed; consistency across study types and across populations including U.S., Bangladesh, China, Taiwan, and Mexico; consistent associations with increased systolic blood pressure or pulse pressure in adults, pregnant women, and children; and coherence with findings for related endpoints like IHD and atherosclerosis. These determinations are presented in the evidence profile table.

As described in the protocol, a structured framework approach is used to draw evidence synthesis judgments for human evidence outlined in Table 3-8 of the protocol (see Section 3.10. of the protocol for more details). The term robust is a characterization for a judgment that the evidence (across studies) supports a conclusion that the effect results from the exposure being assessed. Based on the IRIS handbook, the term robust is used based on “a set of high or medium confidence independent studies (e.g., in different populations) reporting an association between the exposure and the health outcome(s), with reasonable confidence that alternative explanations, including chance, bias, and confounding, can be ruled out across studies. The set of studies is primarily consistent, with reasonable explanations when results differ; the findings are considered adverse (i.e., biologically significant and without notable concern for indirectness); and an exposure-response gradient is demonstrated” (U.S. EPA, 2022). Importantly, 100% consistency is not required to reach a judgment of robust.

[underlined: Public Comment:] One public commenter (Electric Power Research Institute) noted that they cannot figure out which studies are prospective cohort, and which studies are case-control in Figure 3-5. In addition, “page 3–7 states “A selection of these studies will be discussed by study design. A selection of studies that reported effect estimates are summarized in Figure 3-4.” However, case-control studies are grouped with prospective cohort studies (and retrospective cohort studies) within the text. Twenty-seven studies are presented in Figure 3-4, so it is unclear why the term “selection” was used. Furthermore, case-control studies of common diseases (such as CVD) can result in odds ratios that should not be compared to relative risk estimates in cohort studies. There is a rare disease assumption that underlies case-control studies in which odds ratios may reliably estimate relative risks (Rothman et al., 2008; Greenland et al., 1986). Separately, using odds ratios in a dose-response meta-analysis can be problematic because background exposure cannot be determined.”

[underlined: EPA Response:] As described in the newly added Section 1.6.3, “Figures include studies that vary across different dimensions, such as the use of different effect estimates, different exposure assessment techniques as described in the column labeled “Exposure metric,” the use of different reference and exposure groups, and different increments of arsenic for associated regression coefficients. Thus, quantitative comparisons of the magnitude of the associations between studies is not appropriate. The intent of the figures is to facilitate analyses of patterns of associations across studies.” Forest plots are grouped by study design, with the exception that cohort and case-control studies are plotted together for efficiency. However, EPA has added a descriptive column to identify study design for the forest plots that present cohort and case-control studies together. To efficiently examine study results in one place, effect estimates are grouped by ratio measures and difference measures.

The selection criteria for determining which studies (and findings) are plotted are described in the updated text for Section 1.6.3. Every eligible study is now plotted; standardized descriptions of the figures throughout the assessment and how they are organized can be found in Section 1.6.3.

For dose-response, the modeling approach that EPA does not assume that ORs from case-control studies are equivalent to RR from cohort studies for any disease, rare or common. EPA’s modeling approach estimates the prospective likelihood for each type of study (hence the use of the logistic model as discussed fully in Appendix C) and thus avoids concerns over violation of the rare disease assumption that other modeling approaches (i.e., Shao et al. (2021)) would encounter if they modeled common diseases such as diabetes or IHD.

[underlined: Public Comment:] One commenter (Electric Power Research Institute) noted that it is difficult for the reader to locate information about confounders in a study, including which confounders were considered and which were adjusted for in the analysis.

[underlined: EPA Response:] The newly added Section 1.6.2 contains a discussion of some of the common confounders considered for each of the four outcomes described in Evidence Synthesis. Additional detailed information on confounders considered for each study can be found in HAWC. Finally, appropriate consideration of specific confounders (e.g., smoking) was a requirement for studies to be included in dose-response analysis. With respect to smoking, whether a study controlled or accounted for smoking was a critical exclusion criterion, and studies that did not sufficiently consider smoking (through study design or analysis) were excluded from dose-response. The study selection for all meta-analyses is described in Section 4.3.1, “Identification of Studies and Data for Bladder Cancer, Lung Cancer, Diseases of the Circulatory System, and Diabetes dose-response meta-analyses.”

[underlined: Public Comment:] One commenter (Electric Power Research Institute) stated that the key finding for DCS, “Large, prospective cohort studies support exposure-dependent associations of relatively low exposures to iAs in drinking water (<100 mg/L),” should include citations. Further, “it would be helpful to include information on the studies that assessed arsenic in drinking water at low exposures, and whether they were consistent in their findings that there was increased risk of CVD at low exposures.”

[underlined: EPA Response:] Evidence conclusions are summarized in an evidence profile table for each hazard using the considerations outlined in Table 3-5 of the protocol (see Section 3.10. of the protocol for more details) and arrives at an overall level of confidence conclusion based on considering the body of evidence. Evidence profile tables are high level summaries and for more details one should refer to the synthesis narrative sections or the study evaluations located in HAWC. Additionally, new, targeted supplemental data pivots highlighting arsenic drinking water exposures of ≤100 µg/L have been created. These supplemental pivots can be found in Section B.5.

[underlined: Public Comment:] One commenter (Electric Power Research Institute) was unclear if the medium or high confidence studies in the evidence profile table refers to prospective studies, or to the entire body of evidence, including case control studies. “The first column of the evidence profile states that the evidence is based on 27 studies of high or medium confidence. If so, then all studies that the evidence is based on are of medium or high confidence. However, not all studies include low exposures or are prospective cohort studies. It is unclear if this refers to confidence in the conclusion that low-exposure studies also support increased CVD/IHD mortality or only a hazard conclusion of “evidence demonstrates.”” The commenter was also unclear on the details for other factors that increase certainty in the evidence profile table, including consistency, dose-response gradient, large of concerning magnitude of effect, and coherence with findings for related endpoints.

[underlined: EPA Response:] The evidence profile summary for CVD/IHD presented in Table 3-3 is based on 25 medium or high confidence studies of various designs. In this case, the 25 medium or high confidence studies are comprised of 19 case-control/cohort, 3 cross-sectional, and 3 ecological. The evidence synthesis judgment of robust is an overall hazard conclusion that is not targeted to characterizing the low-exposure studies specifically. The US EPA statement that “most studies are medium or high confidence” refers to increased certainty in conclusions for each of the sub-outcomes in that table. This is a judgement across the body of studies. Because the data summarized for each outcome in this table are based on medium and high confidence studies, there is more certainty in the key findings (compared to if the results were from low confidence studies). As described in the protocol, evidence conclusions are summarized in an evidence profile table for each hazard using the considerations outlined in Table 3-5 of the protocol (see Section 3.10. of the protocol for more details) and arrives at an overall level of confidence conclusion based on considering the body of evidence. Evidence profile tables are high level summaries and for more details one should refer to the evidence synthesis and judgement sections.

### F.2.3 SAB Peer Review Comments on Diabetes (Charge Question 3.b)

- 1 Tier 1 Recommended Revisions
- 3 Tier 2 Suggested Revisions
- 0 Tier 3 Future Considerations

#### Tier 1 Recommendations for Charge 3.b

For question 3b, the SAB report states, “The available epidemiological data have been clearly and appropriately synthesized to describe the strengths of the data available for the association between iAs exposure and diabetes. Overall, the weight-of-evidence decision indicating that the evidence demonstrates that iAs causes diabetes is well supported by the epidemiological and animal literature, although some studies showed a null association. The weight-of-evidence decisions for hazard identification are scientifically justified and clearly described and appropriately consider health effects in susceptible subpopulations (e.g., by AS3MT genotype and vitamin B intake for HOMA2-IR; and folate intake as a modifier of iAs metabolism associations with type 1 diabetes).” The report includes several specific comments.

The SAB panel’s tiered comments on Charge Question 3.b were:

- 1 Tier 1 Recommended Revisions
- 3 Tier 2 Suggested Revisions
- 0 Tier 3 Future Considerations

[underlined: SAB Recommendation (1 of 1 Tier 1 for Charge 3.b):] The analysis of type 2 diabetes should be prioritized over type 1 diabetes.

[underlined: EPA Response:] The assessment has been restructured so that type 2 diabetes is the focus of the section. This includes assessment text, with clarification that our hazard identification is based on type 2 diabetes studies. Figures have also been updated to now reflect only type 2 diabetes study results. Studies that aren’t type 2 (e.g., gestational, type 1), are discussed in the Other: Type 1 diabetes and Gestational diabetes sub-section of the Diabetes section. They are also included in literature tag tree for diabetes studies (see Figure 3-22).

#### Tier 2 Suggestions for Charge 3.b

[underlined: SAB Suggestion (1 of 3 Tier 2 for Charge 3.b):] All relevant studies should be included in Figure 3-24, including Kuo et al. (2015). It is not clear to the panel why this study was not included since the study design is very similar to that of Grau-Perez et al. (2017) that was included.

[underlined: EPA Response:] Kuo et al. (2015) has now been added to Figure 3-24. Additionally, text has been added to describe eligibility criteria for which studies and findings appeared in the figures (see Section 1.6.3). Every type 2 diabetes study is now plotted; standardized descriptions of the figures throughout the assessment and how they are organized can be found in Section 1.6.3.

[underlined: SAB Suggestion (2 of 3 Tier 2 for Charge 3.b):] The panel suggests being more descriptive in the selection and reporting of the studies on iAs and diabetes. The panel noted there were 24 studies tagged to this category but fewer than 20 studies shown in Figure 3-24. The panel suggests adding narrative to describe the correspondence between HAWC and what is reported in the assessment. In addition, as noted in other comments, the literature trees could be expanded to reflect each step in the process and the connection to figures/tables throughout the assessment.

[underlined: EPA Response:] EPA has confirmed that every medium/high confidence PECO-relevant study that meets specified figure plotting criteria is included in a forest plot, as discussed in Section 1.6.3. For example, a forest plot was not created if the plot would only display a single estimate. At least two estimates that were generally comparable were required in order to create a plot. Within the section text, studies that were discussed include those determined to be most impactful, including based on cohort size. Additionally, a citation for each study in now included in their respective sub-sections. EPA appreciates the suggestion for tag-tree expansion, but at this time their usage is limited to their current functionality in HAWC.

[underlined: SAB Suggestion (3 of 3 Tier 2 for Charge 3.b):] The evidence stream summary table (see Table 3-4) should be expanded to include all aspects that contribute to the evidence determination that iAs causes type 2 diabetes.

[underlined: EPA Response:] As described in the protocol, evidence conclusions are summarized in an evidence profile table for each hazard using the considerations outlined in Table 3-5 of the protocol (see Section 3.10. of the protocol for more details) and arrives at an overall level of confidence conclusion based on considering the body of evidence. Evidence profile tables are high level summaries and for more details one should refer to the synthesis sections or the study evaluations located in HAWC.

As reflected in the updated narrative for this section, the evidence profile table for this section has been refined to focus exclusively on type 2 diabetes, as the evidence base is primarily for this outcome. Additional detail has been added to the table where possible, including mention of higher and lower exposures.

#### Tier 3 Future Considerations for Charge 3.b

The reviewers had no Tier 3 future considerations.

### F.2.4 Public Comments on Diabetes

[underlined: Public Comment:] One commenter (Students of Johns Hopkins Bloomberg School of Public Health Risk Sciences and Public Policy Institute) recommended EPA review “whether D’Ippoliti et al. (2015) should be cited as the strongest evidence regarding the association between arsenic exposure and diabetes because the analysis does not adjust for individual risk factors like “smoking habits, BMI, and other lifestyle habits” as explicitly stated in the D’Ippoliti et al. (2015) [study].”

[underlined: EPA Response:] EPA does not consider D’Ippoliti et al. (2015) to represent the strongest evidence for demonstrating an association between arsenic exposure and diabetes. EPA has revised its study selection workflow for identifying studies suitable for dose-response analysis (see Section 4.3.1). As part of that study selection process, whether a study controlled or accounted for smoking was a critical exclusion criterion, and studies that did not sufficiently consider smoking (through study design, composition of the population, or analysis) were excluded from dose-response. After consideration of how the D’Ippoliti et al. (2015) study adjusted for smoking on the municipal level (rather than on an individual basis), EPA agrees that the D’Ippoliti et al. (2015) study should be removed from all dose-response meta-analyses.

[underlined: Public Comment:] One commenter (Electric Power Research Institute) noted that more than a third of the studies related to diabetes were published after 2019 and that it is not clear if these post-2019 studies of arsenic and diabetes have any contribution to the hazard assessment, or if any of them are suitable for dose-response consideration. “To take an extreme example, and assuming that the hazard judgment is correct, if most of the post 2019 studies concluded that the risk of diabetes was not increased at low exposure concentrations, it is not clear how these studies would be evaluated in the context of the meta-regression.”

[underlined: EPA Response:] As described in Section 1.6.1. of the assessment, the characterization of newly identified studies from the 2022 literature search update focused on EPA’s judgment of whether studies would have a material impact on the conclusions (i.e., identified hazards or toxicity values) in the external review draft (see Table B-17 in Section B.3 for more details on the literature search update and survey). Diabetes studies identified in the most recent literature search update (August 2022) did not undergo study evaluation because EPA already characterized the strength of the evidence base for diabetes to be robust (based on studies identified up to 2019), and EPA determined that these new studies would not impact the draft hazard conclusion. The SAB concurred with the determination of a robust association between iAs and diabetes, specifically for type 2 diabetes. However, as discussed in Section 4.3, these studies were considered for dose-response utility and evaluated against criteria of particular importance for EPA’s dose-response meta-analysis approach (see the iAs Protocol, Section 5.2.1). Any studies deemed relevant for dose-response based on study design characteristics underwent study evaluation. Any high or medium confidence studies representing any potential exposure level were included in dose-response analyses. Ultimately, no studies identified in the August 2022 literature search were deemed suitable for inclusion in the dose-response meta-analysis for diabetes.

[underlined: Public Comment:] Two commenters (Superfund Settlement Project and RCRA Corrective Action Project) asked when EPA judged that the evidence demonstrates a causal relationship for diabetes. Further, EPA “claims that more than one-third of the studies were not considered for the hazard assessment and did not have useful data for the meta-regression. Even if these studies did not have quantitative dose-response data, these studies may still have important information that informs the dose-response and the overall evidence regarding low exposures. Do any of these studies provide data that conclude that the risk of diabetes was not increased at low exposure concentrations even if the quantitative data were not suitable for meta-regression?”

[underlined: EPA Response:] EPA characterized the strength of the evidence base for diabetes to be robust based on studies identified up to 2019 and determined that these new studies would not impact the draft hazard conclusion (see Table B-17 in Section B.3 for more details on the literature search update and survey). The judgement of robust is an overall hazard conclusion that is not focused on characterizing low exposure concentrations. Hazard conclusions and dose-response analyses are based on medium and high confidence studies that include the full range of exposures.

### F.2.5 SAB Peer Review Comments on Fetal, Newborn, and Infant Health Outcomes (Charge Question 3.c)

The SAB report states, “EPA has clearly and appropriately reviewed the iAs exposure and pregnancy and birth outcomes following the protocol of identifying relevant studies and updated the literature to 2022. EPA examined the quality of the epidemiologic studies by assessing exposure and outcome assessments, biases, and interpretation. The weight-of-evidence is justified, and the interpretation is generally reasonable. The literature on pregnancy and birth outcomes continues to emerge, especially from studies in the US. Therefore, in evaluating whether iAs likely causes these outcomes, it makes sense to turn to the literature on more highly exposed populations along with that of exposures more typical of the US. This is especially the case for outcomes that are rare in the US, i.e., neonatal deaths. The report includes several corrections and suggestions for expanded or clarified discussions on this topic, as denoted in tiered comments (see full report for details).

The SAB panel’s tiered comments on Charge Question 3.c were:

- 2 Tier 1 Recommended Revision
- 7 Tier 2 Suggested Revisions
- 0 Tier 3 Future Consideration

#### Tier 1 Recommendations for Charge 3.c

[underlined: SAB Recommendation (1 of 2 Tier 1 for Charge 3.c):] The panel recommends providing the outcome definition and assessment method for fetal, newborn, and infant health outcomes. The panel recommends renaming the section to fetal, newborn, and infant health outcomes to indicate the focus on fetal and infant but not maternal health outcomes. Further, the panel recommends moving the discussion of preterm birth outcomes to be placed before birth weight.

[underlined: EPA Response:] The section has been renamed to fetal, newborn, and infant health outcomes and this is reflected throughout the document as appropriate. Preterm birth outcomes section has also been moved and is now found before birth weight. When available from the original study, information on outcome definition can be found in the HAWC study evaluation entries. Even if outcome assessment methods may have varied, the study evaluation process probed whether there was confidence that the outcome definition (or assessment criteria) was specific and sensitive, with minimal concern for misclassification.

[underlined: SAB Recommendation (2 of 2 Tier 1 for Charge 3.c):] The context of high or low exposure scenarios of iAs for the fetal, newborn, and infant health outcomes need to be clearly provided. EPA should stratify the exposures by categories to indicate high, moderate, and low exposure scenarios for various perinatal health outcomes.

[underlined: EPA Response:] The recommendation overlaps with “SAB Recommendation (2 of 3 Tier 1 for Charge 2.b” and that response is duplicated here. Not all studies clearly report external exposure levels in environmental media for the populations under investigation. Therefore, EPA is unable to consistently report this information across studies included in the assessment. Where possible, EPA has added context regarding exposure in conjunction with the narrative description of results. To further help address this comment, EPA has provided additional text and Figure 1-1 from Schwarzenbach et al. (2010) in Section 1.5.1. to illustrate general expected exposure levels across the world so that users can have this context as they read the assessment. Building from this, the HAWC forest plots now present the country where the study was conducted. Finally, EPA also presents new, targeted data pivots (found in Section B.5) of studies considered in hazard identification that represent arsenic drinking water exposures of ≤100 µg/L.

#### Tier 2 Suggestions for Charge 3.c

[underlined: SAB Suggestion (1 of 7 Tier 2 for Charge 3.c):] The panel suggested that gestational length or gestational age be considered on the causal pathway to birth weight in the evaluation of studies on birth weight.

[underlined: EPA Response:] Gestational length/age may be on the causal pathway between arsenic exposure and birth weight. In response to the panel suggestion, the primary meta-analysis presented in the updated assessment focuses on studies that do not adjust for gestational length/age, given that it may be a mediator. EPA also presents a sensitivity analysis with a larger group of studies that includes those that did adjust for gestational age. Results were similar between the two analyses. Additional details can be found in Section 4.4.

[underlined: SAB Suggestion (2 of 7 Tier 2 for Charge 3.c):] EPA should distinguish cross-sectional from prospective studies consistently in the figures and text.

[underlined: EPA Response:] EPA has reviewed this section to make any necessary clarifications regarding study design.

[underlined: SAB Suggestion (3 of 7 Tier 2 for Charge 3.c):] Discrepancies in the inclusion of studies in the forest plots across outcomes should be corrected. The difference in study inclusion when one study that examined multiple outcomes was not included in the figures of all examined outcomes should be explained.

[underlined: EPA Response:] EPA has cross-checked studies and plots, and the updated version of the assessment includes all reported outcomes from studies if there was more than one set of results to present in a relevant plot. In other words, a figure was not created if the figure would only display a single estimate. At least two estimates that were generally comparable were required in order to create a figure. Additional details on the approach to plotting can be found in newly added text in Section 1.6.3.

[underlined: SAB Suggestion (4 of 7 Tier 2 for Charge 3.c):] EPA should provide a balanced statement for the use of urinary iAs as the biomarker. The urinary biomarker may reduce misclassification if speciation of arsenic was used and arsenobetaine was excluded from analysis.

[underlined: EPA Response:] Text regarding exposure assessment method, in particular urinary speciation, has been aggregated and expanded upon in Section 1.6.2. In this section, EPA has added a statement to indicate this potential advantage of using urinary biomarkers: “… urinary biomarker may reduce misclassification if speciation of arsenic was used and arsenobetaine was excluded from the data analysis.”

[underlined: SAB Suggestion (5 of 7 Tier 2 for Charge 3.c):] EPA should acknowledge that some studies did not find significant associations with adverse fetal, newborn, and infant health outcomes when synthesizing the evidence.

[underlined: EPA Response:] EPA considers this incorporated into the assessment. Examples of such text, among many others in the section, include:

- “They did not observe an association between neonatal mortality at any level of arsenic exposure (Rahman et al., 2007).”
- “No association was observed between arsenic exposure and spontaneous abortion.” (von Ehrenstein et al., 2006)
- “In another cross-sectional study, Kwok et al. (2006) observed no association between iAs drinking water levels (exposure categories ranging from 0 to >300 µg/L) and stillbirth in Bangladesh.”

[underlined: SAB Suggestion (6 of 7 Tier 2 for Charge 3.c):] EPA should provide context for the finding from Figure 3-31(b) on page 3-78 that shows a relatively large regression coefficient and confidence intervals for the inverse association for the Kile 2016 study that is distinct from other studies.

[underlined: EPA Response:] As stated in newly added text in Section 1.6.3, “The intent of the figures is to facilitate qualitative analyses of patterns of associations across studies. Figures include studies that vary across different dimensions, such as the use different types of effect estimates, different exposure assessment techniques as described in the column labeled “Exposure metric,” the use of different reference and exposure groups, and different increments of arsenic for associated regression coefficients. Thus, quantitative comparisons of the magnitude of the associations between studies is not appropriate.” In response to this question specifically, Kile et al. (2016) presents effect estimates based on a per natural-log (ln) unit increase in exposure, while Bloom et al. (2016) in the same figure presents estimates based on a per 10 unit increase in exposure. With this context, Kile et al. (2016) does not appear to be an outlier.

[underlined: SAB Suggestion (7 of 7 Tier 2 for Charge 3.c):] EPA should include risk modifiers, particularly pre-pregnancy BMI and nutritional status, in reporting associations between iAs exposure and infant health outcomes.

[underlined: EPA Response:] The revised assessment includes the following additional risk modifiers to the fetal, newborn, and infant health outcomes section in Table 3-6: nutritional status, smoking status, and maternal pre-pregnancy weight. However, it should be noted that Table 3-6 displays only selected examples of potential risk modifiers identified from studies reviewed in the assessment as well as other studies identified in a targeted literature search. This table is not meant to be comprehensive.

#### Tier 3 Future Considerations for Charge 3.c

The reviewers had no Tier 3 future considerations.

### F.2.6 Public Comments on Fetal, Newborn, and Infant Health Outcomes

[underlined: Public Comment:] One commenter (Superfund Settlement Project and RCRA Corrective Action Project) noted that the post-2019 studies were excluded based on “lack of hazard and/or dose-response utility,” although EPA reported that these studies underwent risk of bias.

[underlined: EPA Response:] Post-2019 studies were not excluded from the analysis. As described in Section 1.6.1, EPA characterized the strength of the evidence base to be moderate for fetal, newborn, and infant health outcomes based on studies identified up to 2019. Studies identified in the 2022 literature update for fetal, newborn, and infant health outcomes were evaluated to determine if they might change the hazard conclusion of moderate. As part of this evaluation, the post-2019 studies for these health outcomes underwent risk of bias evaluation. Medium and high confidence studies identified from the 2022 literature search update are discussed in the synthesis section for fetal, newborn, and infant health outcomes. Separately, as part of screening studies for dose-response utility, consideration was given to study design characteristics and certain risk of bias judgments, i.e., whether the study considered key confounding factors, such as smoking.

[underlined: Public Comment:] One commenter (Superfund Settlement Project and RCRA Corrective Action Project) noted that the 13 studies that evaluated fetal and infant mortality (see Figure 3-27 of the assessment) were given an overall confidence rating of probably low risk of bias and/or definitely low risk of bias. “The different domains assessed should not be weighted equally. Of particular importance are those domains related to exposure characterization and confounding. In this example (see Figure 3-27 of the assessment), 7 studies were rated “probably high risk of bias” for exposure characterization; 2 studies were rated “probably high risk of bias” for confounding or effect modification that was not accounted for in the design or analysis; and 5 studies were rated “probably high risk of bias” for confounding that was not assessed consistently across groups using reliable measures. Separately, the study by Myers et al. (2010) was identified as having a” probably high risk of bias” for six domains (comparison group, confounding, adjusting for other exposures, consistent assessment of confounding, exposure characterization, and outcome characterization) of the total 11 domains. The overall justification for a confidence rating of “probably low risk of bias” should be justified for these studies. There is no additional information in HAWC that justifies the overall confidence ratings. It would be helpful to identify the most important sources of bias for the body of literature and describe how the studies addressed them.”

[underlined: EPA Response:] Text in Section 1.6.2 has been clarified to indicate that study evaluations are holistic judgments based on all domains that are considered. A judgment of deficient (or the equivalent in the prior system for study confidence) in one domain does not necessarily mean that the entire study is low confidence or unsuitable for dose-response. There are no pre-set weights for the domains. and study reviewers are responsible for applying expert judgment to make the determination of overall study confidence rating.” Because the process of study evaluation inherently involves expert judgment, each study is independently reviewed by at least two epidemiologists and any differences of opinions on domain judgements are resolved through discussion or consultation with other epidemiologists. When the overall study confidence rating was not clearly evident from the individual domain ratings, EPA has added new text to the overall confidence rating in HAWC to clarify. EPA agrees with the commenter that the exposure characterization and confounding domains are especially critical. Newly added text in Section 1.6.2 describes key confounders relevant to each health outcome in the hazard identification section.

For the Myers et al. (2010) study specifically, EPA has reviewed the HAWC study evaluation and provided targeted updates. Specifically, three domains that were previously rated as “probably high risk of bias” (comparison group; consistent assessment of confounding; outcome characterization) were reclassified to “probably low risk of bias.” Text justification for these specific domains and the overall domain rating is provided in HAWC.

[underlined: Public Comment:] One commenter (Electric Power Research Institute) noted that in the forest plot for CVD/IHD incidence and mortality (see Figure 3-5) there is one study of congenital heart defects (Jin et al., 2016) included, and this study should fall under developmental outcomes.

[underlined: EPA Response:] Given that congenital heart defects are considered developmental outcomes, this study has been reclassified and is now found in the “other” section of the fetal, newborn, and infant health outcomes literature tag tree. This group of outcomes is not discussed further in the assessment text.

### F.2.7 SAB Peer Review Comments on Neurodevelopmental Effects (Charge Question 3.d)

For question 3d, the report did not include an overarching description of the panel’s disposition on this topic, although the sole Tier 1 recommendation summarized, “Overall, the synthesis of the evidence on neurodevelopmental outcomes is well organized and reported. However, while cross-sectional studies of concurrent exposure measurements may provide a reasonable proxy for exposure during an etiologically relevant period, the weight of evidence is not the same as cohort studies to determine the role of prenatal and early postnatal exposure. It is recommended that EPA include more cohort studies with prenatal and early childhood exposure assessments of iAs.”

The SAB panel’s tiered comments on Charge Question 3.d were:

- 1 Tier 1 Recommended Revisions
- 4 Tier 2 Suggested Revisions
- 1 Tier 3 Future Considerations

#### Tier 1 Recommendations for Charge 3.d

[underlined: SAB Recommendation (1 of 1 Tier 1 for Charge 3.d):] “Overall, the synthesis of the evidence on neurodevelopmental outcomes is well organized and reported. However, while cross-sectional studies of concurrent exposure measurements may provide a reasonable proxy for exposure during an etiologically relevant period, the weight of evidence is not the same as cohort studies to determine the role of prenatal and early postnatal exposure.” EPA should include more cohort studies with prenatal and early childhood exposure assessments of iAs. The panel noted the following recent prospective studies on neurodevelopmental outcomes: Patti et al. (2022); Dai et al. (2023); Notario-Barandiaran et al. (2023); and Butler et al. (2023). Further, the cohort study findings were listed after the cross-sectional studies and should be presented in more detail emphasizing distinct windows of exposure.

[underlined: EPA Response:] EPA has changed the order of this section to discuss cohort studies before cross-sectional studies. EPA has also included periods of exposure in the discussion of cohort studies where possible. Moreover, a literature update was conducted in August 2024, which allowed for inclusion of additional recent studies, including newer cohort studies (Patti et al., 2022; Lozano et al., 2024; Dai et al., 2023; Butler et al., 2023).

#### Tier 2 Suggestions for Charge 3.d

[underlined: SAB Suggestion (1 of 4 Tier 2 for Charge 3.d):] In the evidence judgment section (page 3-122), while it is true that exposure levels of <100 µg/L primarily showed cognitive effects, EPA should indicate the inverse association was observed at a level much lower than 100 µg/L.

[underlined: EPA Response:] Text in the Evidence Judgment section has been modified to indicate that this association was observed at much lower levels: “This conclusion is based on studies of humans that assessed exposure levels much lower than 100 µg/L (e.g., including <10 µg/L) primarily showing cognitive effects and, to a lesser extent, social, behavioral, and emotional effects, and motor effects.” Additionally, new, targeted, supplemental data pivots (found in Section B.5) have been created to highlight low dose exposure (i.e., studies with arsenic drinking water exposure of ≤100 µg/L).

[underlined: SAB Suggestion (2 of 4 Tier 2 for Charge 3.d):] EPA states that “Many of the cross-sectional studies evaluated populations that had experienced chronic or lifelong exposure to arsenic, and thus the concurrent exposure measurements are expected to be a reasonable proxy for exposure during an etiologically relevant period.” The reasoning does not accurately reflect critical internal concentrations in the blood and developing brain due to differential distribution and metabolism during the perinatal period.” Differential absorption, distribution, metabolism, and excretion and critical windows for neurodevelopmental susceptibility in the perinatal period should be discussed in more detail.

[underlined: EPA Response:] Additional context on elevated exposure during critical windows and differential ADME in relation to arsenic susceptibility has been added to Section 1.5.1 and Section 3.2.4 (Evidence from Epidemiological Studies; developmental neurocognitive effects: cohort and case control studies).

[underlined: SAB Suggestion (3 of 4 Tier 2 for Charge 3.d):] A study on attention deficit hyperactivity disorder (ADHD) is presented in Figure 3-41 that summarizes studies on cognition. It is not clear why estimates for ADHD present confidence intervals (see Figure 3-41, panel c, of the assessment), whereas forest plots appear without confidence intervals for Bayley outcomes of cognitive, language, motor, social-emotional, and adaptive skills in Figure 3-41, panel b. A footnote should be added to indicate if they are visible or not available.

[underlined: EPA Response:] The study identified by the SAB, Jiang et al. (2022), has now been plotted with other studies with continuous exposures which allows for better visualization of the confidence intervals. EPA has added text outlining the criteria for including studies in figures (see Section 1.6.3). Tier 3 Future Considerations for Charge 3.d

[underlined: SAB Suggestion (4 of 4 Tier 2 for Charge 3.d):] The panel noted that there are newer studies that could be included that focus on iAs in the context of metal mixtures (Stein et al., 2022; Valeri et al., 2017; de Water et al., 2022; Doherty et al., 2020), as well as a study that looks at how the infant gut microbiome alters neurodevelopmental susceptibility to iAs exposure (Laue et al., 2022). “Additionally, Soler-Blasco et al. (2023) found that creatinine-corrected urinary iAs and metabolites monomethylarsonic acid (MMA) and dimethylarsinic acid (DMA) collected during pregnancy corresponded to decrements in several neuropsychological scores at the age of 4−5 years and were associated with polymorphisms contributing to susceptibility to iAs.” These newer studies could be considered for updating the assessment, especially if they contribute to dose-response analysis of neurodevelopmental outcomes. Also, neurodevelopmental effects should not be discussed without the context of birth weight.

[underlined: EPA Response:] Studies that evaluated iAs in the context of metal mixtures do not meet the PECO criteria for this assessment; only studies that also report an individual effect estimate for arsenic are PECO-relevant. Examples of risk modifiers are provided in Table 3-8. EPA recognizes that the impacts of arsenic on the microbiome is an emerging area of interest [e.g., (Laue et al., 2022; Dheer et al., 2015)]. With regard to the impact of birth weight on neurodevelopmental effects, EPA has added text in Section 1.6.2 to acknowledge the potential role as a mediator or confounder.

#### Tier 3 Future Considerations for Charge 3.d

[underlined: SAB Future Consideration (1 of 1 Tier 3 for Charge 3.d):] EPA should consider more recent MOA/AOP studies that were performed at doses and concentrations much more relevant to human exposures in the U.S., like Nino et al. (2019). The current mechanistic observations section does not portray the current literature on iAs MOA. “For example, the highlighted citation Herrera et al. (2013) used relatively blunt methodology at extremely high exposure levels (50 mg/L GD1-LD21) to achieve a measurable response. Additional studies are cited that also use very high exposure levels to implicate changes of glucocorticoid receptor and draw parallels to endocrine effects reported by Wasserman et al. (2007).”

[underlined: EPA Response:] While the Nino et al. (2019) study was conducted at concentrations more relevant to human exposure in the U.S., this study uses an Ahlzeimer’s mouse model and there are no other arsenic studies that have used this model. EPA agrees that mechanistic studies conducted at human relevant concentrations would be useful and represents a research gap that could be considered in future experimental studies.

### F.2.8 Public Comments on Neurodevelopmental Effects

[underlined: Public Comment:] One commenter (Students of Johns Hopkins Bloomberg School of Public Health Risk Sciences and Public Policy Institute) noted that “in the Evidence Judgement section, which states on pg. 3-122 lines 2–4 that the given evidence indicates that inorganic arsenic exposure “likely causes neurodevelopmental effects in humans given sufficient exposure conditions,” no elaboration is given on what is meant by “sufficient exposure conditions.”

[underlined: EPA Response:] EPA acknowledges that some level of exposure is needed to elicit effects, and this is defined in dose-response analyses. This is footnoted throughout the assessment as “The “sufficient exposure conditions” are more fully evaluated and defined for the identified health effects through dose-response analysis in Section 4.”

[underlined: Public Comment:] One commenter (Students of Johns Hopkins Bloomberg School of Public Health Risk Sciences and Public Policy Institute) noted that there is limited ability to appropriately characterize exposure time based on sampling methods. “The review states on pages 3-103, lines 3–6: “Many of the cross-sectional studies evaluated populations that had experienced chronic or lifelong exposure to arsenic, and thus the concurrent exposure measurements are expected to be a reasonable proxy for exposure during an etiologically relevant period.” However, Wasserman et al. (2014) notes one of the limitations of their 2014 study, which was used for the dose-response modeling, was an inability to retrospectively characterize the exposure to drinking water arsenic levels across the lifespan,” as “only few children had resided in the present home for their entire lives.” However, the same analysis was done excluding children who had relocated to their current home in less than five years yielded the same results, and the results from EPA’s dose-response model were excluded for other reasons. Additionally, this study collected data on arsenic levels in home drinking water but no data on the water drinking habits of the subjects. As a result, the analyses from this study cannot account for water consumed while away from home or the amount of water consumed while at home. Wright et al. (2006) also suggests that using hair concentrations to measure chronic exposure to arsenic may not be the most appropriate tissue but does not recommend an alternative.”

[underlined: EPA Response:] All approaches to assess exposure have strengths and limitations, see expanded text in Section 1.6.2. As such, the assessment does not draw conclusions based on a single study but instead looks across the body of evidence based on the entire collection of data, each with their own strengths and weaknesses. EPA observed similar findings across different exposure assessment methods, including drinking water and biomarkers of exposure (urine, hair, nail, and blood), which minimizes concern about impact of potential exposure misclassification for any single exposure characterization approach on the overall hazard conclusion. Additionally, EPA has expanded the neurodevelopmental dose-response modeling to be based on a meta-analysis of multiple studies rather than modeling on a single study. Wasserman et al. (2014) is no longer used in dose-response modeling for neurodevelopmental outcomes. The candidate value for developmental neurocognitive effects (based on a meta-analysis of three studies) is 0.102 µg/kg-day.

[underlined: Public Comment:] One commenter (Students of Johns Hopkins Bloomberg School of Public Health Risk Sciences and Public Policy Institute) recommended including influence of maternal education status and socioeconomic status as a risk modifier. “Wasserman et al. (2014) discusses the potential influence that increased maternal education may impart, as increasing public awareness of environmental contamination may cause households to avoid certain behaviors or practices that may increase risk of exposure. The populations studied by both Parvez et al. (2011) and Wright et al. (2006) are located in areas associated with hazardous waste sites or lead mining, which can indicate populations with lower socioeconomic status, as these populations may be forced to remain in areas with high risk of contamination due to lower housing costs or an inability to relocate.“

[underlined: EPA Response:] Possible modifying factors were identified by reviewing the epidemiological studies in the hazard sections, along with studies identified from a targeted literature search. Table 3-8 contains a summary of selected risk modifiers identified from these sources, but this table is not intended to be comprehensive. Additionally, risk modifiers are only able to be identified in this table if studies present separate numerical results for the identified risk modifiers. Wasserman et al. (2014), Parvez et al. (2011), and Wright et al. (2006) did not provide separate numerical results, so EPA was unable to include in Table 3-8.

[underlined: Public Comment:] Two commenters (Superfund Settlement Project and RCRA Corrective Action Project and Electric Power Research Institute) noted that “the post-2019 studies were excluded based on “lack of hazard and/or dose-response utility,” although the USEPA reported that these studies underwent assessment for risk of bias. This “lack of hazard and/or dose-response utility” statement is confusing.” One commenter (Superfund Settlement Project and RCRA Corrective Action Project) noted that the justification for the overall confidence ratings were not provided in HAWC and that “ratings of “probably high risk of bias” for some of these domains are more important than other domains and the likely impacts should be addressed in the overall confidence rating.”

[underlined: EPA Response:] The assessment has been revised to clarify the workflow for the studies identified after 2019, see “SAB Recommendation (2 of 3 Tier 1 for Charge 2.a).” EPA characterized the strength of the evidence base to be moderate for neurodevelopmental health outcomes based on studies identified up to 2019. Studies identified in the 2022 literature update for neurodevelopmental outcomes were evaluated to determine if they might change the hazard conclusion of moderate. As part of this evaluation, the post-2019 studies for this health outcome underwent risk of bias evaluation. Medium and high confidence studies identified from the 2022 literature search update are discussed in the synthesis section for neurodevelopmental health outcomes. Separately, as part of screening the newly identified medium and high confidence studies for dose-response utility, consideration was given to study design characteristics and certain risk of bias judgements, i.e., whether the study considered key confounding factors, such as smoking. Additional details on the screening criteria for dose-response of neurodevelopmental studies can be found in Section 4.5. If studies did not meet these criteria, they were considered to have “lack of dose-response utility.”

Additional information on developing overall confidence ratings is provided in newly expanded text in Section 1.6.2, Overall Study Confidence Determination. There are no defined weights for the domains, and study reviewers are responsible for applying expert judgment to make the determination of overall study confidence rating. Because the process of study evaluation inherently involves expert judgment, each study is independently reviewed by at least two epidemiologists and any differences of opinions on domain judgements are resolved through discussion or consultation with other epidemiologists. In addition, text has been added to HAWC in a targeted manner to clarify overall confidence ratings in scenarios where the overall confidence judgment was not self-evident from the individual domain ratings.

### F.2.9 Additional Public Comments on Hazard Identification

[underlined: Public Comment:] One commenter (Electric Power Research Institute) noted that “although the draft Review may be making reasonable conclusions regarding the evidence synthesis judgments (“evidence demonstrates” or “evidence indicates”) …. the information has not been provided in a format that allows the reader to see the support for these judgements and confirm they are scientifically justified by citing specific studies, or identifying the likely impact of bias, or by providing information on confounding factors that were adjusted for in the analyses.”

[underlined: EPA Response:] The methods underpinning the evidence synthesis of epidemiological evidence is described in Section 3.10 of the Updated Problem Formulation and Protocol. As described in the Protocol, evidence conclusions are summarized in an evidence profile table for each hazard using the considerations outlined in Table 3-5 of the protocol (see Section 3.10. of the protocol for more details) and arrives at an overall level of confidence conclusion based on considering the body of evidence. Evidence profile tables are intended to be high level summaries only; for more details on the key findings from a particular study, one should refer to the synthesis sections, forest plots, or the study evaluations located in HAWC. The SAB concurred with the evidence synthesis judgment reached by EPA.

[underlined: Public Comment:] One commenter (Simplot) noted that the “Draft Toxicological Review (USEPA 2023) did not control for or perform a sensitivity analysis on many key confounding exposures besides iAs that might be causal factors for the diseases it evaluated. It is stated that a sensitivity analysis was performed to assess the effects of potential confounders, but the confounders discussed included age, body mass index (BMI), educational attainment, etc. Many of the studies did include information on smoking status, an important confounder for lung and bladder cancer. However, many of the major risk factors for the health endpoints of interest were not discussed in the document at all.” The commenter points to other risk factors for lung cancer, including radon, asbestos, uranium, cadmium, chromium, nickel, petroleum products, and airborne fine particles. Similarly for bladder cancer, the commenter points to aromatic amines, paints, rubber products, hair dyes, diesel fumes and other health conditions as risk factors.

[underlined: EPA Response:] A new subsection, “Impact of Other Factors,” in Section 1.6.2, was added and contains a discussion of some of the common confounders considered for each of the four outcomes described in Evidence Synthesis. Section 1.6.2 also contains a discussion of the study evaluation process that considers confounding. As the commenter indicates, full consideration of potential confounding by co-exposures can be difficult to achieve in any individual study, e.g., consideration of co-exposures associated with the health outcome of interest. For this reason, most individual studies were considered probably low risk of bias rather than definitely low risk of bias in the respective domain. However, evidence synthesis judgments are based on a body of evidence, where limitations in certain studies can be offset findings from other studies. Additional details on the study evaluation process can be found in the Protocol (see Section 3.9 of the assessment). Study evaluations for the arsenic assessment did incorporate outcome-specific considerations, as is standard for IRIS assessments. In addition, for dose-response, smoking was considered a key confounder, and only studies that appropriately considered smoking were used in the dose-response meta-analyses.

[underlined: Public Comment:] One commenter (Superfund Settlement Project and RCRA Corrective Action Project) noted that the presentation of the data makes it difficult to assesses whether the “evidence demonstrates” or “evidence indicates” hazard assessments are scientifically justifiable. Specifically, they point to the forest plot visualizations and how the exposure comparisons and units differ widely.

[underlined: EPA Response:] The commenter has raised this same issue for the cardiovascular disease health outcome, see public comments on charge question 3.a. Evidence conclusions are summarized in narrative and in an evidence profile table for each hazard using the considerations outlined in Table 3-5 and Section 3.10 of the protocol. arrives at an overall level of confidence conclusion based on considering the body of evidence. Evidence profile tables are intended to be high level summaries only; for more details on the key findings from a particular study, one should refer to the synthesis sections, forest plots, or the study evaluations located in HAWC. “Evidence demonstrates” or “evidence indicates” is a qualitative conclusion based on consideration of factors such as consistency, exposure-response relationship, strength of the association, temporal relationship, coherence, and “natural experiments” in humans (U.S. EPA, 1994; U.S. EPA, 2005a). Further, conclusions on consistency, precision, and evidence of exposure gradient are based on the pattern of findings across studies. These conclusions can be drawn even if the exposure comparison and units differ.

With regard to figures, as stated in Section 1.6.3, they “include studies that vary across different dimensions, such as the use different effect estimates, different exposure assessment techniques as described in the column labeled “Exposure metric,” the use of different reference and exposure groups, and different increments of arsenic for associated regression coefficients. Thus, quantitative comparisons of the magnitude of the associations between studies is not appropriate. The intent of the figures is to facilitate analyses of patterns of associations across studies.” To increase clarity on dose-response gradient, each hazard section now includes a list of studies that identified a pattern of a dose-response relationship. These patterns can also be observed in the forest plots within the assessment. While many studies did identify suggestive dose-response gradients, not every study did. Overall, most studies did observe a dose-response gradient. Some variation in the pattern of results is expected across any body of evidence. When dose-response gradient is detected in many studies, this is reflected in the evidence profile tables as a factor that increases certainty in conclusions drawn from evaluating a body of studies assessing the same outcome.

[underlined: Public Comment:] One public commenter (USA Rice) stated that “contrary to the NASEM recommendation (Chapter 7 of the 2013 Formaldehyde Report) for integration of all the lines of scientific evidence, IRIS relies on epidemiology and ignores human biology.” Another public commenter (Electric Power Research Institute) stated that “the draft Toxicological Assessment’s reliance only on epidemiology evidence and using animal and mechanistic evidence as potential supplemental material, is inconsistent with Agency guidance. The NRC (NRC, 2014) has explicitly stated that evidence integration is typically performed considering human, animal, and mechanistic evidence. Consideration of only epidemiological studies eliminates studies that may be critical in characterizing the shape of the dose-response curve at low concentrations, considering that epidemiological studies of low exposure concentrations frequently show risks that are not distinguishable from the null for a variety of reasons (for example, differences in inter individual variability in diseases or related to physiological processes that affect internal doses).”

[underlined: EPA Response:] The decision to focus on the epidemiological studies was outlined in the 2019 Protocol and was supported by the NASEM review panel (NASEM, 2019). As discussed in the Protocol and Section 1.6 of the assessment, MOA analyses are typically applied for chemicals for which human evidence is insufficient or human relevance needs to be established. EPA Cancer Guidelines (U.S. EPA, 2005a) state that “data from epidemiologic studies are generally preferred for characterizing human cancer hazard and risk.” Further, modeling in the range of observed human exposures reduces the uncertainty in risk estimates. Given the availability of informative, low-dose human data for iAs, extrapolation below observed levels is not needed. This approach presented in the protocol was supported by the NRC (2013) and underwent peer review by NASEM in 2019 (NASEM, 2019). NASEM (2019) agreed that “MOA information will not contribute directly to determine the shape of the dose-response curve based on epidemiological data.” Moreover, the reliance on human evidence is consistent with assessments by others (TCEQ, 2017; EFSA, 2009; ATSDR, 2007).

[underlined: Public Comment:] One public commenter (Exponent, Inc.) stated that “Epidemiological data from studies should not be at incorporated at face value without adequate consideration of the underlying factors that may influence these data. Issues with these epidemiological data have been discussed by the recent review by Tsuji et al. (2019) and some examples are briefly noted below. Please see Tsuji et al. ((Tsuji et al., 2014a; Tsuji et al., 2014b; Tsuji et al., 2015; Tsuji et al., 2019)) for more detailed information on specific studies and issues.”

[underlined: EPA Response:]Tsuji et al. (2019) discusses consideration of confounding factors and effect modifiers, like tobacco use, nutritional status, and water intake. Systematic bias, residual bias, and uncontrolled confounding are considerations in the study evaluation process that all studies in the assessment underwent prior to inclusion. Additional details on the study evaluation process as well as examples of key confounders considered for each health outcome are described in Section 1.6.2. Studies that advanced from hazard identification to dose-response were considered to be at low risk for systematic bias, residual bias, and uncontrolled confounding at the overall study level, i.e., of medium or high confidence. Additional details for each specific study can be found in HAWC.

[underlined: Public Comment:] Two public commenters (USA Rice and National Cotton Council of America) criticized the assessment for not providing evidence tables, “denying the public the ability to fully understand the science upon which the assessment is based” and “how the assessment was created”

[underlined: EPA Response:] The basis for the comment is unclear as the assessment provides summary evidence profile tables (with accompanying narrative), forest plots that display core study design and findings from individual studies, and interactive study evaluation “heat maps” with access to the rationales underpinning study evaluation judgements. The methods used in the assessment were described in Updated Problem Formulation and Protocol for the Inorganic Arsenic IRIS Assessment describes the methods used to develop the assessment, including how synthesis sections are developed. This protocol underwent review by the NASEM in 2019 (NASEM, 2019). In addition, the evidence synthesis methods use in the iAs assessment are consistent with those presented in the IRIS Handbook, which also underwent NASEM review (NASEM, 2021). As described in Section 3.10 of the protocol, Evidence Synthesis of Epidemiological Evidence, each synthesis is written to provide a discussion of the available evidence that addresses considerations that may suggest causation adapted from (Hill, 1965). Table 3-5 in Section 3.10 summarizes information most relevant to describing primary considerations informing causality during evidence syntheses. Evidence profile tables in each synthesis section provide a summary of the evidence and interpretation leading to the evidence synthesis judgement. Study evaluation ratings and forest plots of considered studies are included in the assessment and can be found in HAWC. Individual study methods and findings presented in the forest plots are also available in HAWC and can be downloaded.

## F.3 CHARGE QUESTION 4–META-REGRESSION ANALYSES

4) EPA performed dose-response meta-analyses, herein referred to as meta-regression (MR) analyses on bladder cancer, lung cancer, diseases of the circulatory system (DCS), and diabetes and presents the results of these analyses in Section 4.3.
  a) Please comment on whether the application of a MR analysis and methods used to select studies for the MRs are clearly described and scientifically justified. If there are additional publicly available studies that warrant consideration as the basis of these analyses, please identify those studies, and outline the rationale for including them in the assessment.
  b) Please comment on whether the modeling approaches for the MR analyses, including calculation of effective counts, estimation of iAs intake values that account for background oral and dietary exposures, the choice of logistic regression for modeling response probabilities, and hierarchical Bayesian methods to estimate pooled slopes of the relationship between extra risk and dose, are scientifically justified and clearly described.
  c) In applying the hierarchical Bayesian model, EPA selected priors for the pooled MR slope such that the pooled slope could not be negative, reflecting the causal determinations for bladder cancer, lung cancer, diseases of the circulatory system, and diabetes. Please comment on whether this decision is scientifically justified and scientifically justified and clearly described.

### F.3.1 SAB Peer Reviewer Comments on selecting studies for meta-regression analysis (Charge Question 4.a)

The SAB report states, “The application of a meta-analysis approach is valuable for pooling results across studies to estimate a dose-response function, has well-established precedent in epidemiology as the gold standard for evidence synthesis, and is well-justified. The meta-analysis approach is especially valuable and appropriate for synthesizing evidence to estimate human dose-response estimates for a toxicant like iAs that has a large epidemiological literature base, many simultaneous toxicity mechanisms and targets making the toxicology literature much more complex to evaluate, and where observed human responses appear to differ from simplified experimental systems for many outcomes, further making the toxicological literature challenging to interpret. The SAB agrees with EPA’s approach as being scientifically justified and appropriate to rely on human evidence, synthesized through meta-analysis, as the basis for the dose-response estimation.” The SAB panel report also noted, regarding the inclusion of studies with different exposure metrics in the meta-analysis, that “As a result, combining studies that are affected by different types of bias including studies of arsenic biomarkers and studies of water arsenic is a strength as it allows one to assess the robustness of the findings across different metrics of exposure, affected by different types of bias.” However, the panel included as tiered comments several recommendations for EPA to expand the analyses to more fully and transparently consider other potentially relevant studies (including those based on alternative exposure biomarkers), outcomes, and susceptible populations or lifestages (see full report for details).

The SAB panel’s tiered comments on Charge Question 4.a were:

- 2 Tier 1 Recommended Revision
- 1 Tier 2 Suggested Revisions
- 0 Tier 3 Future Consideration

#### Tier 1 Recommendation for Charge 4.a

[underlined: SAB Recommendation (1 of 2 Tier 1 for Charge 4.a):] Consider inclusion of other outcomes from studies that meet the criteria (e.g., RRP below 10) for dose-response modeling. This particularly pertains to cancer outcomes for which quantitative risk estimation is the primary goal (e.g., skin cancers, skin lesions). Provide justification for any that are excluded.

[underlined: EPA Response:] The current iAs IRIS assessment has an extensive history of scoping and problem formulation activities, extending back to the mid-2000s. This includes engagement with EPA programs and regional offices, external peer review input and public comments received on prior draft assessments that were not finalized, and additional external scientific input via workshops, webinars, and other types of meetings (see “Chemical Documents” on the inorganic arsenic landing page). Given the vastness of the literature on arsenic, EPA was encouraged to prioritize health outcomes for inclusion in the IRIS assessment.

The results of this extensive scoping and problem formulation were summarized in a 2019 protocol, which presents the systematic review and dose-response methodologies used to develop the draft assessment. The protocol also presented a list of health outcomes prioritized for dose response (bladder cancer, lung cancer, disorders of the circulatory system, pregnancy and birth outcomes and diabetes) that were identified based on prior NASEM input as well as additional analyses presented in the 2019 protocol, i.e., the dose-response screening and “relative risk to background exposure” (RRB) analyses discussed below. This protocol was reviewed by NASEM in July 2019 (NASEM, 2019). The NASEM panel did not recommend modeling of additional health outcomes. Additionally, no public comments were received indicating that additional health outcomes should be modelled. A summary of the prioritization process for health outcomes is presented below.

Initially, EPA prioritized which health outcomes to focus on in the current assessment based on the National Research Council’s 2013 Critical Aspects of EPA’s IRIS Assessment of Inorganic Arsenic report (NRC, 2013), in which the NRC categorized several health outcomes into three tiers. The 2013 NRC report advised EPA to further refine these categories after conducting more comprehensive analyses. EPA did so by using existing assessments and new systematic review analyses to characterize the strength of the evidence for the 12-tiered health outcomes as robust, moderate, or slight. Health outcomes that were characterized as robust or moderate included cancers of the bladder, lung, kidney, liver, and skin and noncancer effects on the circulatory system (ischemic heart disease, hypertension, and stroke), reproductive system (including pregnancy and birth outcomes), developmental outcomes (including neurodevelopmental toxicity), endocrine system (including diabetes), immune system, respiratory system, and skin. These outcomes generally aligned with the NRC’s Tier 1 (evidence of causal association) or Tier 2 (other priority outcomes) outcomes and were further explored in the RRB analysis discussed below. Outcomes characterized as slight (prostate cancer, pancreatic cancer, and renal disease) were not considered further.

EPA further refined the set of prioritized outcomes by conducting a dose-response screening analysis to identify outcomes and studies that warranted more complex dose-response analyses, i.e., the hierarchical Bayesian dose-response meta-analysis with lifetable estimation of lifetime extra risk presented in the assessment. As part of this screening analysis, over 250 datasets across twelve outcomes were modeled with EPA’s Benchmark Dose Software to estimate the relative risk over background (RRB) exposure using either a study-specific background exposure level (if available) or the U.S. background exposure level. The full details of this analysis are presented in Appendix A and have been published in Hobbie et al. (2020). The lower an RRB value is for a study, the greater the concern for that health outcome because it demonstrates increases in relative risk at exposure levels close to U.S. background exposure levels. Ultimately, the screening level RRB analysis demonstrated that, out of the twelve health outcomes considered, diseases of the circulatory system, bladder cancer, and lung cancer were identified as having multiple individual study RRB values close to one and median RRB values less than 10. These health outcomes were also identified as having the largest databases suitable for additional dose-response modeling. In addition, consultation with EPA program and regional offices during scoping and problem formulation also identified diabetes, pregnancy and birth outcomes, and neurodevelopmental effects as health outcomes particularly important to EPA benefit-cost analyses. Thus, these outcomes were added to the list of prioritized outcomes.

The above information and prioritization decisions are included in EPA’s systematic review protocol document (Appendix A) and were reviewed by the NRC in their 2019 review. The NRC panel “agree[d] with EPA’s approach to prioritizing the health outcomes and its decision to focus dose-response analyses on the outcomes with robust or moderate evidence of a causal association.” Regarding the use of the RRB screening analysis to make decisions about selecting outcomes for further dose-response analyses, the committee recommended the additional information on the application of the RRB analysis be added to the protocol (and subsequent assessment). The NRC panel also “encourage[d] consideration of exposure in guiding decisions within the risk assessment…” The NASEM panel did not specifically object to the ultimate prioritization decisions (i.e., focusing dose response on bladder cancer, lung cancer, diseases of the circulatory system, diabetes, pregnancy outcomes, and neurodevelopment) and did not request that additional specific outcomes (e.g., skin cancer, skin lesions) be included in the prioritized list of dose-response outcomes.

In response to the SAB recommendation, EPA evaluated whether any skin cancer or skin lesion studies would make it through the study selection process for dose-response (see Sections 1.6.4 and 4.2.1), high and medium confidence skin cancer and skin lesion studies were identified. Of the 31 high and medium confidence skin lesion studies, only two studies (conducted in the same population) made it through the study selection process (Lindberg et al., 2008; Lindberg et al., 2010). However, the study population analyzed these publications was conducted in a very high exposure population with the reference group exposure defined as less than 80 µg/L. A single high-dose study is not likely to be a driver for risk in the assessment. For skin cancer, of the 25 high and medium confidence studies considered, three studies reporting iAs-induced basal cell and/or squamous cell carcinoma (BCC and SCC, respectively) made it through the study selection process. One study reported they collected smoking data but it was unclear how or if those data were used in the analysis. If that study were excluded, that would leave one study each for BCC and SCC. Thus, with only one study for each type of skin cancer, inclusion of these studies in a dose-response analysis is unlikely to drive the ultimate dose-response conclusions of the assessment.

[underlined: SAB Recommendation (2 of 2 Tier 1 for Charge 4.a):] Consider inclusion of studies of gestational urinary arsenic and studies on children.

[underlined: EPA Response:] EPA has evaluated a study recommended by the panel (Gilbert-Diamond et al., 2016) and determined it provides an approach for converting maternal urinary total As (tAs) concentrations (both adjusted for urine dilution or not) into daily drinking water exposure (in units of µg/day inorganic As). As such, studies of pregnancy outcomes (i.e., birth weight) and neurodevelopmental cognition that used maternal urinary tAs as the dose metric are now considered for inclusion in dose-response analyses for these outcomes. Studies that used childhood urinary (or hair) tAs as the dose-metric for neurodevelopmental outcomes are still excluded from consideration given the uncertainty surrounding converting these biomarker concentrations into drinking water exposures. The relationship between urinary tAs and drinking water iAs concentrations, presented in the El Masri- Kenyon PBPK model (El-Masri and Kenyon, 2008) for adults was not applied to childhood urinary tAs concentrations because the age range in the population used in the El Masri and Kenyon PBPK model (El-Masri and Kenyon, 2008) excluded children. The El Masri and Kenyon PBPK model (El-Masri and Kenyon, 2008) was based on people aged 17–92 years (median 36 years for HEALS cohort, median 61 years Churchill County cohort), whereas the age of children in epidemiologic studies of neurodevelopment were typically under 16. The consideration of maternal urinary tAs studies for neurodevelopmental studies resulted in over 20 additional studies being assessed for their suitability for dose-response and point of departure estimation. Further, the SAB panel provided a comment in Appendix B of the SAB report (not included in the main report): “[g]iven concerns raised above, an assessment of the more recently published literature identifying neurodevelopmental health impairments associated with iAs exposure seems warranted.” In response to this comment, EPA conducted an updated targeted literature search in 2024 for any neurodevelopmental studies published since the last literature search. Of the more than 1,000 studies found (see Section 2; Figure 2-2), 15 total studies were identified as PECO-relevant after screening and were further evaluated for possible inclusion in dose-response analyses. Of these 15, one additional study (Chen et al., 2023) was considered suitable for dose-response. Thus, of the total body of neurodevelopmental studies screened for dose-response analysis, three studies were considered suitable for dose-response modeling, one identified from the 2024 targeted literature search and two from the previously identified literature (see Section 4.5).

#### Tier 2 Suggestions for Charge 4.a

[underlined: SAB Suggestion (1 of 1 Tier 2 for Charge 4.a):] Review studies identified as relevant (included in hazard identification, but not meta-analysis) to confirm no usable associations are presented in Supplemental Materials for those papers.

[underlined: EPA Response:] The study selection section) describing which studies were considered for dose-response analyses and inclusion/exclusion criteria has been substantially revised in the assessment (see Sections 4.3.1, 4.4, and 4.5 and Figures 4-2, 4-3, 4-4, 4-5, 4-10, and 4-11). As part of this evaluation, supplemental materials for studies, if available, were evaluated for potentially usable association information. Analysis of supplemental materials did not result in the additional of additional data sets for dose-response, but occasionally provided information germane to results presented in the main study (e.g., results presented graphically in main study but numerically in supplemental materials).

#### Tier 3 Future Considerations for Charge 4.a

The reviewers had no Tier 3 future considerations.

### F.3.2 SAB Peer Reviewer Comments on modeling approaches for meta-regression analysis (Charge Question 4.b)

The SAB comments on this charge question were subdivided by bulleted topic, as summarized below (see full report for details). The SAB panel included recommendations and suggestions related to each of the bulleted topics as tiered comments.

- Effective counts: “The SAB agreed that the method [used by EPA] was scientifically justified, though some equations and definitions require clarification.”
- Estimation of iAs intake values that account for background oral and dietary exposures: “The SAB agrees that conversion of dose to a common metric in μg/kg-day was a scientifically justified approach to support the meta-analysis, which requires a common metric to combine the epidemiological studies.” However, while the SAB agreed with such conversions, including through use of PBPK modeling, the SAB did recommend specific corrections on this topic and made several suggestions for improvement.
- Choice of logistic regression for modeling response probabilities: “The EPA used a logistic regression model for dose-response modeling because it can integrate case-control and cohort data into the same analysis. The SAB believes this justification is reasonable but are concerned about the restrictions imposed by the logistic model, particularly the monotonicity imposed as well as the lack of a lower threshold. The EPA performed extensive sensitivity analyses of the monotonicity assumption comparing their simple linear-in-the-logit model to fractional polynomial and double hill models. The SAB commends the EPA for those explorations but believes the justification for selecting their simpler model is lacking particularly when the alternative models provided superior fit.”
- Hierarchical Bayesian methods to estimate pooled slopes of the relationship between extra risk and dose: “Overall, the SAB agrees that the EPA’s Bayesian meta-regression is a scientifically justified approach for combining slope estimates from multiple studies and is well described. However, revisions are still needed to ensure that the method is accessible to a broader audience.” The SAB raised several additional concerns, as follows.
  ○ “The SAB also raised a concern about the two-stage approach used to fit their models.”
  ○ “The SAB believes that the sensitivity analyses performed by the EPA provides a rigorous assessment of the influence of individual studies on the meta-regression. However, there was general agreement within the SAB that additional model diagnostics are needed.”
  ○ “Finally, the SAB has concerns about the appropriateness of certain data for the meta-regression.”

The panel provided tiered recommendations and suggestions related to the transparency, accessibility, and clarity of these analyses.

The SAB panel’s tiered comments on Charge Question 4.b were:

- 6 Tier 1 Recommended Revision
- 11 Tier 2 Suggested Revisions
- 1 Tier 3 Future Considerations

The peer review comments above were sub-organized by SAB in their report according to the following content areas: Effective Counts (0 Tier 1, 2 Tier 2, 0 Tier 3), Estimation of Intake (1 Tier 1, 5 Tier 2, 0 Tier 3), Logistic model (1 Tier 1, 1 Tier 2, 0 Tier 3), Bayesian methods (4 Tier 1, 3 Tier 2, 1 Tier 3).

#### Tier 1 Recommendations for Charge 4.b

[underlined: SAB Recommendation (1 of 6 Tier 1 for Charge 4.b):] Augment the analysis to include those studies correcting biomonitoring data for dilution with specific gravity instead of urinary creatinine.

[underlined: EPA Response:] With the exception of a few pregnancy outcome studies (see response to 7th Tier 1 recommendations for Charge Question 6 on the choice of Kile et al. (2016) study for EPA’s pregnancy outcome dose-response analysis), the majority of the urinary biomarker studies that made it through EPA’s dose-response study selection corrected for urinary dilution by dividing by urinary creatinine concentration. Thus, a robust sensitivity analysis to determine whether creatinine or specific gravity is a more appropriate approach is not currently possible. Separately, this issue has investigated by multiple studies (Hsieh et al., 2019; Kuo et al., 2022) which have concluded that, conceptually and observationally, creatinine adjustment is a practical and valid approach to adjust for urinary dilution. A discussion of urinary concentration correction methods has been added to Section 1.6.2 of the assessment.

[underlined: SAB Recommendation (2 of 6 Tier 1 for Charge 4.b):] Use a fit statistic that penalizes for model complexity (e.g., AIC or BIC) to determine if the simple linear logistic model is sufficient for an individual outcome, or if a more flexible alternative model is needed.

[underlined: EPA Response:] A more flexible form of the logistic model, herein called the “logistic-power” model, with the form Pr ( D = 1 | X ) = (1)/(1 + e ^ ( − α * − β ( x^q^ )^′^) , has been applied in the main dose-response analysis in revised assessment. The q parameter is a non-hierarchical model parameter that is estimated in the MCMC simulation and is constrained to positive values. It can take the value of one, which would result in the logistic model, but can also take large values (>18) that would result in essentially a threshold model. The inclusion of the q parameter confers greater flexibility (compared to the logistic model) and allows the logistic-power model to fit a more sigmoidal dose-response shape, if sufficiently supported by the dose-response data. The value of the power term is estimated via updating in the Bayesian dose-response meta-analysis framework, so that it is informed by the dose-response data being modeled and not set a priori. Given that the logistic model is a degenerate form of the logistic-power model, the assessment does not present results from both models and then select between the two. Rather, the results for only the logistic-power model are now used in the main analysis. In instances where the logistic-power model fitting results in a mean power parameter value greater than one, the results for the simpler logistic model are presented as a sensitivity analysis to simply to demonstrate how model results differ between the two models (see Sections 4.3.5 through 4.3.8 and relevant endpoint-specific sensitivity analyses in Section C.1.2). Given that there is no longer the need to select between two models in the main analysis (as only the logistic-power model was considered for the main analysis), neither the AIC or BIC has been used in the revised assessment to inform model selection between simpler models (i.e., logistic model) or more complex models in the main analysis (i.e., logistic-power model). Regarding sensitivity analyses investigating low-dose non-monotonicity using the fractional polynomial or double Hill models and showing superior fit with more complex models: the superior fits (confirmed by the calculation of the BIC statistic, see Section C.1.1: Sensitivity Analysis of Possible Non-monotonic Dose-Response Relationships: Results) observed were from application of particular forms of the factional polynomial model where response asymptotically approaches infinity as dose approaches zero. EPA acknowledges that, while selection of the prior attempted to ameliorate this behavior, these models should have been excluded from consideration a priori given this toxicologically and biologically infeasible behavior. Ultimately, EPA recognizes the superior statistical fit of these two forms of the fractional polynomial model compared to the simple logistic model, but ultimately decided to not use this model in the main analysis given the revised strategy of using the logistic-power model. As stated above, the use of the logistic-power model was adopted to account for the possibility of threshold-like behavior in the dose-response. While this model is more flexible than the logistic model, it cannot take on non-monotonic dose-response curves. However, this is not seen as a necessity given the results of the non-monotonic sensitivity analysis (see Section C.1.1: Sensitivity Analysis of Possible Non-monotonic Dose-Response Relationships) where no non-monotonic behavior was observed at doses close to or above background exposures. The methods description and results of the non-monotonic sensitivity analysis has been updated to reflect this change.

[underlined: SAB Recommendation (3 of 6 Tier 1 for Charge 4.b):] Provide a more practical and accessible explanation of the meta-regression model including a diagram of the hierarchical structure.

[underlined: EPA Response:] The description of the implementation of the hierarchical model (included in Section C.1.1) has been revised in the dose-response appendix. As part of this revision, a diagram of the hierarchical structure of the model has been added.

[underlined: SAB Recommendation (4 of 6 Tier 1 for Charge 4.b):] Provide theoretical support for the continuous approximations to the binomial and Poisson distributions used to construct the likelihood, either through citations to peer reviewed publications or by adding detailed derivations to the supplementary materials.

[underlined: EPA Response:] In the external peer review draft of the assessment, the log-likelihoods for the cohort were based on continuous extensions of the Poisson distribution. This extension allows one to consider non-integer inputs to that distribution, such as the effective counts that were derived to account for adjustments to the reported relative risks or odds ratios. References supporting the continuous extension of the Poisson distribution have been added to the final draft of the assessment (Turowski, 2010; Kim et al., 2010; Ilienko, 2013).

For the case-control studies, the derivation of the likelihood is explicitly described in the supplemental material (see Section C.1.1) and is not dependent on, nor is it an extension of, the Binomial distribution. The derivation of the likelihood (see Eq C-15) makes no assumptions about the observations being integers, and so is applicable even to fractional counts, as derived during calculation of effective counts.

In both cases, revised text with additional explanation has been added to the dose-response appendix (see Section C.1.1; Bayesian Dose-Response Meta-Analysis Methods).

[underlined: SAB Recommendation (5 of 6 Tier 1 for Charge 4.b):] Provide convergence diagnostics for all outcomes included in the assessment.

[underlined: EPA Response:] Convergence diagnostics (N_eff values, Rhat values, and numbers of divergent transitions) are generated as results by the Bayesian hierarchical model (as implemented in RStan). In the final draft of the assessment, N_eff and Rhat values for bladder cancer, lung cancer, IHD, and diabetes are included in the modeling summary tables for all outcomes and divergent transitions (if any) are reported. When divergent transitions exceed 0.1% of total post warm-up draws, pairs plots are generated to investigate the distribution of divergent transitions in the posterior. If divergent transitions are judged to be localized randomly in the distribution and are less than 0.5% of the total post warm-up draws (and no convergence issues are suggested by poor Rhat values), model performance is judged to be adequate.

[underlined: SAB Recommendation (6 of 6 Tier 1 for Charge 4.b):] Examine goodness-of-fit using posterior predictive plots.

[underlined: EPA Response:] The plots that display the mean and 95% credible intervals for the fitted model predictions for the individual studies are the basis for posterior predictive plots and examining goodness-of-fit. Those plots have been generated without the hierarchical structure in order to avoid the tendency for the study-specific estimates to be pushed toward the hierarchical mean of the slope parameter. But, otherwise, they represent the posterior predictions, on a study-by-study basis, relative to the observed odds ratios (for case-control studies) or relative risks (for cohort studies). EPA has also opted to display the frequentist-based, adjusted confidence intervals reported by the study authors. That is important in this case to give some perspective on the uncertainty in the observations, and how that varies from study to study. Moreover, given that EPA is fitting models that are monotonic (increasing OR or RR as dose increases), it is important to visualize the uncertainty when the best estimates of the OR or RR are not monotonic within any given study.

In short, the plots provided, which compare the ranges of both observed and predicted ORs and RRs, in a study-specific and dose-related manner provide summary predictive plots relevant to the dose-response analysis under consideration.

#### Tier 2 Suggestions for Charge 4.b

[underlined: SAB Suggestion (1 of 11 Tier 2 for Charge 4.b):] Revise the definition of expected effective counts in cohort studies to be consistent with the equation provided.

[underlined: EPA Response:] The definition for expected effective counts presented in Section 4.3.3 and C.1.1 was revised as necessary to be consistent with the equations provided in the assessment.

[underlined: SAB Suggestion (2 of 11 Tier 2 for Charge 4.b):] Where appropriate (e.g., equations 6 and 7 [in Section C.1]), replace RR with adjusted RR to clarify how effective count calculations were performed in cohort studies.

[underlined: EPA Response:] The equations have been revised in the assessment.

[underlined: SAB Suggestion (3 of 11 Tier 2 for Charge 4.b):] Revise the IRIS document to clarify that PBPK models provided the scientific basis for the dose conversions but were not directly used to estimate daily dose.

[underlined: EPA Response:] The assessment has been revised in Section 4.1 (see footnote25) to clarify that the El-Masri-Kenyon PBPK model (El-Masri and Kenyon, 2008) provided the scientific basis for assuming that a 1:1 relationship exists between urinary tAs concentrations and drinking water iAs concentrations in adults and that the PBPK model was not directly used to convert urinary concentrations to drinking water concentrations. Additionally, the text throughout the final assessment was revised to clarify that it is the empirical relationship between urinary tAs concentrations and drinking water concentrations that was used to do the dose conversions.

[underlined: SAB Suggestion (4 of 11 Tier 2 for Charge 4.b):] The equation for calculation of dose from urinary biomarker studies should be provided and discussed in the text, and not just in the table.

[underlined: EPA Response:] The equation used to convert creatinine-adjusted urinary tAs concentrations to drinking water iAs concentrations has been added and discussed in the text of Section C.1.1 and included in Table C-2 (along with all other equations used to perform dose-conversions).

[underlined: SAB Suggestion (5 of 11 Tier 2 for Charge 4.b):] Add “per day” to units for factors used in the dose calculations where appropriate (e.g., mg/kg-day; mg/L-day”).

[underlined: EPA Response:] Dose conversion equations, exposure factors, and reported dose metrics have been revised as necessary to make clear they pertain to “per day” doses, when appropriate. This has usually been done by adding “daily” so the description of the dose reads “daily iAs intake (µg/kg-day)” or something equivalent.

[underlined: SAB Suggestion (6 of 11 Tier 2 for Charge 4.b):] The dose conversion equations in the text, tables, and elsewhere (e.g., EXCEL files) need to be reviewed and corrected. The text currently describes the equations for cumulative drinking water exposure in mg/L*years and daily dose in mg/day but could be expanded to specify equations for the other metrics used including water concentration in mg/L and cumulative exposure in mg.

[underlined: EPA Response:] All dose conversion equations in the text, tables, and dose-conversion spreadsheets have been thoroughly reviewed and revised so that they accurately report the correct units for exposure factors and actual conversion equations used to estimate daily iAs intake (in units of µg/kg-day). In addition, although specific worked examples were included in the assessment to demonstrate the dose-conversion approach, equations for converting other dose metrics into daily intake values have been added (even when no worked example is provided for that dose metric), see Table C-2.

[underlined: SAB Suggestion (7 of 11 Tier 2 Charge 4.b):] All the calculation spreadsheets should be independently reviewed as an additional QA/QC step to ensure they are correct, and the terminology is consistent between the documents and the spreadsheets in light of the numerous editorial comments made on the document.

[underlined: EPA Response:] All dose-conversion worksheets have been reviewed to ensure that the correct conversion is applied and that terminology between the assessment document and spreadsheets is consistent.

[underlined: SAB Suggestion (8 of 11 Tier 2 Charge 4.b):] Expand sensitivity analyses to include models with a lower threshold effect for iAs exposure.

[underlined: EPA Response:] A more flexible form of the logistic model, herein called the “logistic-power” model, has been applied in the main dose-response analysis in the revised assessment (see response to SAB Recommendation 2 of 6 Tier 1 for Charge 4.b). The inclusion of the q parameter confers greater flexibility (compared to the logistic model) and allows the logistic-power model to fit a more sigmoidal dose-response shape. If sufficiently supported by the dose-response data, the logistic-power model yields a dose-response shape that has a flatter shape at low doses (approximating a more extreme threshold behavior) before the classic logistic model sigmoidal shape becomes evident. Therefore, the logistic-power model is more flexible than the logistic model (when the q parameter >1) or degenerates to the logistic model (when q parameter = 1), and implementation of the logistic-power model confers increased ability to model dose-response data when threshold-like behavior is evident. This more flexible form of the logistic model is used in the main dose-response analysis of the revised assessment and not limited to a sensitivity analysis. However, in instances where model fitting results in a q parameter >1, the results for the simpler logistic model (i.e., q parameter = 1) are presented as a sensitivity analysis to compare results.

[underlined: SAB Suggestion (9 of 11 Tier 2 for Charge 4.b):] Examine differences between participant characteristics in the studies included in the meta-regression and the target population for the assessment. If differences exist, perform an analysis examining the impact of demographic factors on study-specific slopes.

[underlined: EPA Response:] EPA has expanded upon previous sensitivity analyses to include a discussion of study-specific characteristics such as betel nut usage, seafood consumption, or other important factors where possible or necessary (see endpoint-specific leave-one-out sensitivity analysis results in Section C.1.2). Fully incorporating study-specific demographics like age profile, sex profile, etc. into the current Bayesian meta-analysis framework as additional explanatory variables would require a high level of effort and would represent a significant modification of the existing dose-response methods. Given that all four endpoints modeled using the Bayesian hierarchical model contain US populations (or populations reasonably expected to be demographically similar to the US or US sub-populations, i.e., European, Mexican, Chilean populations), concern that there are stark demographic differences between individual studies that would greatly impact the modeling results is lessened. As EPA continues to develop dose-response methods for epidemiological data for future assessments, incorporation of demographic characteristics will be a focus of methodological research.

[underlined: SAB Suggestion (10 of 11 Tier 2 for Charge 4.b):] When multiple studies from the same population are included in the same meta-regression model, examine the impact of the population on the overall slope by re-running the analysis with these studies excluded.

[underlined: EPA Response:] Usage of multiple studies from the same population was a consideration in the revised study selection workflow to select studies for inclusion in the dose-response meta-analysis, i.e., studies using the same cohort population or case-control studies using the same recruited population. When multiple studies covered the same study population, only a single representative study was used in the dose-response meta-analysis. For cohort studies conducted using the same cohort population, studies that included a longer follow-up period were generally preferred. However, in some cases studies with shorter follow up were selected for inclusion if other characteristics favored their use over other studies. For example, the Yang et al. (2013) cohort study of bladder cancer in Northeastern Taiwan was conducted in the same cohort population as Chen et al. (2010b) and had three additional years of follow-up. This would typically have resulted with the Yang study being preferred for inclusion. However, the Chen study was ultimately selected for inclusion as it had more dose-groups. Datasets with more dose-groups are generally preferred in dose response analyses as they are assumed to better describe the dose-response pattern. Another example pertinent to case-control studies is the Wu et al. (2013) bladder cancer study. This study was selected for inclusion in the bladder cancer dose-response meta-analysis and represented a population recruited from Taiwanese hospitals between September 2002 and May 2009. A number of other case-control studies of bladder cancer were conducted in study populations drawn from the same hospitals with overlapping time periods, e.g., Huang et al. (2008b) included a study population drawn from a hospital included in the Wu et al. (2013) study but covered a narrower time frame of September 2002 and May 2004. Given the likely inclusion of cases and/or controls in both studies, Wu et al. (2013) was ultimately selected as the single study from these hospital-based case control studies included in the dose-response meta-analysis given it had a longer period of case identification and included more cases of bladder cancer in its analysis. Note that when two case-control studies are conducted in the same geographic population, both are included in the dose-response meta-analysis if they fulfill the above requirement of non-overlapping recruitment periods and all other study-selection criteria. For example, both Steinmaus et al. (2012) and Ferreccio et al. (2000) were conducted in study populations recruited from the same Northern Chile region including Antofagasta in order to investigate iAs effect on lung cancer. Unlike the Taiwanese studies above, both of the Chilean studies were deemed appropriate to include the dose-response meta-analysis because their times of recruitment were far apart: October 2007 to December 2010 for Steinmaus et al. (2012) and November 1994 to July 1996 for Ferreccio et al. (2000). Thus, a reasonable inference is that the same study participants did not participate in both studies. Dose-response meta-analyses including studies of the same study population were not conducted in the iAs assessment because this violates the independence assumption of the of the meta-analysis.

[underlined: SAB Suggestion (11 of 11 Tier 2 for Charge 4.b):] Clearly describe the minimal data standards required for the meta-regression, include the minimum number of studies.

[underlined: EPA Response:] Text was added to the assessment indicating the minimum number of studies required for a meta-analysis was three (see Section 4.3.1).

#### Tier 3 Future Consideration Charge 4.b

[underlined: SAB Future Consideration (1 of 1 Tier 3 for Charge 4.b):] Perform an extensive simulation study examining the impact of ignoring the estimation error of the expected counts and exposure on BMD and BMDL estimation.

[underlined: EPA Response:] This future consideration refers to SAB discussion of EPA’s approach to estimating both expected counts and dose group means in the “pre-analysis” phase and then model these inputs as observed values (and not estimated) in the hierarchical dose-response phase of the analysis. Although this is an accurate description of the modeling workflow, the assessment does not “ignore” uncertainty in the pre-analysis phase. Namely, when estimating dose group means from reported exposure ranges, the maximum likelihood estimates of dose group means were used in the “main” analysis, but “low” and “high” estimates of dose were included in sensitivity analyses to investigate the impact of dose estimation uncertainty on the final dose-response results (see endpoint-specific sensitivity analysis results in Section C.1.2). These sensitivity analyses did not suggest that exposure uncertainty exerts a large impact on modeling results. When systematically lower doses are used in the dose-response analysis, pooled logistic slopes never increase by more than 31%. Conversely, when systematically higher doses are used, the pooled logistic slope never decreases by more than 25%. While a simulation analysis using a one-stage approach where the pre-analysis and analysis phases of the dose-response modeling are combined could provide additional consideration of uncertainty and bias, the current sensitivity analyses based on the pre-analysis phase does not suggest undue uncertainty (i.e., the magnitude of differences in modeling results was no more than approximately 30% between the “main,” “low dose,” and “high dose” sensitivity analyses for any endpoint; lung cancer saw the greatest difference where the pooled slope was 30.2% greater than that for the MLE doses).

### F.3.3 SAB Peer Reviewer Comments on application of the hierarchical Bayesian model (Charge Question 4.c)

The report states, “The SAB agrees that the use of a Gamma prior on the overall mean is supported by a substantial evidence base that iAs exposure should increase risk of the outcomes analyzed. However, this assumption can place undesirable restrictions on the analysis that are not supported by the data from the individual studies.” The panel included two suggestions as tiered comments on this topic.

The SAB panel’s tiered comments on Charge Question 4.c were:

- 0 Tier 1 Recommended Revision
- 2 Tier 2 Suggested Revisions
- 0 Tier 3 Future Considerations

#### Tier 1 Recommendation for Charge 4.c

The reviewers had no Tier 1 recommendations.

#### Tier 2 Suggestions for Charge 4.c

[underlined: SAB Suggestion (1 of 2 Tier 2 for Charge 4.c):] Perform sensitivity analyses remove the positivity restriction on the prior for the overall mean slope.

[underlined: EPA Response:] In the main analysis, the logistic-power model uses a gamma distribution for the prior over the pooled logistic slope parameter (i.e., bmean), reflecting the weight of evidence determination that iAs exposure is causal for the development of bladder cancer, lung cancer, diabetes, and IHD. The gamma distribution prior has the greatest density of prior weight on bmean values close to zero and inspection of the posterior distribution for this parameter for all modeled endpoints reveals that the distribution still places high weight on small values (reflecting that many study-specific slope distributions place high weight on negative values). To investigate the degree to which the positivity constraint the gamma distribution places on the estimation of the bmean parameter, an alternative analysis was conducted using a normal (N(0,1)) distribution for the bmean parameter, meaning that this parameter can now take on both negative and positive values after the hierarchical dose-response. Modeling of all four endpoints reveals two consistent characteristics: (1) the left tail of the posterior distribution does indeed contain negative values (the 2.5th lower bound of the posterior for all endpoints was negative), and (2) the mean of the normal posterior distribution was greater than the mean for the gamma posterior distribution. Thus, while the use of a normal prior distribution for the bmean parameter does result in the posterior distribution spanning zero and returning negative values, the mean and upper bound lifetime extra risks resulting from modeling with this prior results in marginally (~18%–36%) increased mean risks compared to the main analysis. The endpoint-specific sensitivity analysis sections in Section C.1.2 have been updated with the results of this sensitivity analysis.

[underlined: SAB Suggestion (2 of 2 Tier 2 for Charge 4.c):] Clearly list the values of parameters a and b used in the sensitivity analyses for the gamma prior.

[underlined: EPA Response:] The parameters of the alternative Gamma prior distributions have been added to the tables reporting the results of the sensitivity analyses in the final draft of the assessment (see Tables C-29, C-40, C-48, and C-57 in the endpoint-specific sensitivity analysis results in Section C.1.2).

#### Tier 3 Suggestions for Charge 4.c

The reviewers had no Tier 3 future considerations.

### F.3.4 Public Comments on Meta-regression Analyses (Charge Question 4)

#### Creatinine adjustment and other aspects of interpreting urinary arsenic studies

[underlined: Public Comments:] One commenter (Exponent) provided multiple comments regarding EPA’s use of epidemiologic studies that used creatinine-adjusted urinary concentrations as the exposure metric. The comments are summarized here and available in submitted format in the public EPA docket (EPA-HQ-ORD-2012-0830). Exponent asserted that creatinine adjustment can confound the association between arsenic exposure and health effects. For example, the commenter stated that low glomerular filtration and albuminuria are both associated with bladder cancer and lung cancer and that lower urinary creatinine levels associated with these conditions as well as low lean body mass will increase the creatinine adjusted urinary arsenic concentrations. This commenter further stated that use of creatinine will tend to increase the adjusted arsenic concentration for more susceptible populations with lower urinary creatinine levels, including underweight individuals, those with low folate and protein status, diabetics, and others with impaired kidney function. Specifically, regarding kidney function, this commenter noted that diabetes may mediate or confound the association between arsenic and cardiovascular disease in that diabetes can result in reduced urinary creatinine through impairment of kidney function, thus leading to the appearance of higher arsenic exposure through higher creatinine corrected urinary arsenic levels.

[underlined: EPA Response:] Urine samples used to assess arsenic exposure are typically adjusted to correct for dilution of the samples due to the variable hydration status of study participants. EPA recognizes that all adjustment concentration correction approaches have their own strengths and weaknesses (see Section 1.6.2). A number of published studies support the use of creatinine adjustment, and an expanded discussion has been added to Section 1.6.2. Ultimately, the SAB panel agreed with EPA’s use of creatinine-adjusted urinary biomarker studies for the Bayesian dose-response meta-analysis, noting that because “… data have shown that urinary arsenic corrected by urinary creatinine is more closely correlated with blood arsenic and water arsenic, compared to urinary arsenic corrected by specific gravity …,” that “…urinary arsenic corrected by urinary creatinine is an adequate method to correct spot urine samples for urine dilution.” (see page 25 of the final SAB report)

More generally, as stated in 1.6.2, “it is not possible to pick a clear “best” approach for all scenarios. Urine-creatinine levels can be influenced by factors including age, sex, muscle mass, body mass index, and comorbidities such as diabetes (Barr et al., 2005). Similarly, specific-gravity adjustment has limitations in individuals with kidney damage, metabolic conditions (including diabetes), or cardiovascular disease (Maull et al., 2012; Kuo et al., 2022). Therefore, when outcomes under study are also potentially impacted by factors related to urine-creatinine or specific gravity, judgement is required to select the most appropriate adjustment approach for a given outcome. In this assessment, lack of urinary correction (either urinary creatinine or specific gravity) was considered during study evaluation in the exposure characterization domain. However, lack of accounting for urinary dilution was not on its own considered a limitation that would preclude consideration of the study for hazard characterization (when applicable) or dose-response analysis. Yet, for the final dose-response analyses, all studies incorporated an approach to correct for urinary dilution. If one urinary correction approach was not available, estimates using the alternative approach were carried forward for dose-response based on expert judgment. However, as described in Section 4, there were also scenarios where the outcome-specific dose-response methods dictated the preference for a specific type of urinary correction adjustment approach. More specifically, the El-Masri-Kenyon PBPK model established an empirical relationship between drinking water exposure and creatinine-adjusted urinary total As concentrations (see Section 4.1). As such, only studies that reported creatinine-adjusted urinary concentrations were suitable for dose-conversion and inclusion in the Bayesian dose-response meta-analysis.”

[underlined: Public Comment:] One commenter (Exponent) indicated that assessment of arsenic exposure based on biomarkers (e.g., urine) is complicated by the metabolism of inorganic arsenic to methylated forms, some of which are also contributed by dietary sources of other arsenic forms. As a specific example, this commenter also stated that diabetics may have higher intake (and thus excretion) of relatively non-toxic forms of arsenic (i.e., DMA) and recommended that studies that report apparent associations between cardiovascular disease or diabetes and total speciated urinary arsenic levels because of elevated DMA, but not because of elevated inorganic arsenic or MMA, do not provide evidence of a causal association of these diseases with inorganic arsenic.

[underlined: EPA Response:] The EPA’s RfD and CSF estimates for arsenic represent risk associated with μg/kg body weight increases of drinking water (not dietary) arsenic intake. A population-specific baseline dietary exposure is assumed, and all of the increases in exposure (across dose-groups) are assumed to be due to iAs that is consumed from drinking water. For urinary biomarker studies, it is assumed that the increases in total urinary arsenic are predominantly due to increases in drinking water exposures and that there is an approximate 1:1 relationship between the total urinary arsenic mg/day and the mg/day oral consumption of arsenic (see Section 3.1.1). An additional discussion of how studies addressed dietary sources of organic arsenic via seafood is provided in Section 1.6.2.

With respect to DMA, while DMA is less toxic in comparison to other forms of arsenic it is not generally characterized as “relatively non-toxic” (Davydiuk et al., 2023). Larger amounts of urinary DMA could be excreted due to arsenosugars exposure, such as through seafood consumption. EPA is not aware of any data to support the commenter’s assertation regarding increased intake of DMA among potential diabetics. DMA is also produced via inorganic arsenic metabolism. Ultimately the toxicity of each arsenic metabolite does not change based on its exposure route to the body. Therefore, the sum of urine iAs and methylated arsenic species (MMA and DMA) is an appropriate biomarker to examine the association between arsenic exposure and diabetes.

[underlined: Public Comment:] One commenter (Exponent) noted that blood arsenic measures are typically not speciated and will be influenced by organic arsenic compounds in the diet and that blood arsenic concentrations are also increased in individuals with lower methylation capacity because of deficiencies in dietary intake of folate and other nutrients.

[underlined: EPA Response:] EPA appreciates the concerns raised, but blood arsenic studies are not used in dose-response analyses.

#### Residual Confounding

[underlined: Public Comment:] One commenter (Exponent) recommended that adequate control for tobacco or betel nut use is essential for valid assessment of associations of low-level arsenic exposure with many diseases because of the much greater effect of these substances on relevant health outcomes such as bladder cancer, lung cancer, and cardiovascular disease, compared to low levels of arsenic. This commenter noted that accurate adjustment for smoking is difficult and often leaves residual confounding and recommended that associations restricted to never smokers provide important information on dose-response relationships that are not confounded by smoking. Further, this commenter objected to the inclusion of one cohort in particular (D’Ippoliti et al., 2015) that was unable to adjust for smoking on the individual level but did so based on regional cigarette sales.

[underlined: EPA Response:] Very few iAs epidemiological studies restrict analyses to never smokers or betel nut users. Consideration of the potential for residual confounding in epidemiological research is considered in the study evaluation process (see Section 1.6.2) and the results of individual study evaluations are reported throughout the hazard identification section in endpoint-specific study evaluation heatmaps (for example, see Figure 3-8). Consideration of smoking specifically is discussed in Section 1.6 and in numerous other locations in the assessment. The hazard identification study evaluations, including whether a study had sufficient control for confounders, informed studies selected for dose-response (see Section 4.3.1).

EPA has clarified its study selection workflow for identifying studies suitable for dose-response analysis. As part of that study selection process, whether a study controlled or accounted for smoking was a critical exclusion criterion, and studies that did not sufficiently consider smoking (through study design, composition of the population, or analysis) were excluded from dose-response. After consideration of how the D’Ippoliti study adjusted for smoking on the municipal level (rather than on an individual-by-individual basis), EPA agrees that the D’Ippoliti study should be removed from all dose-response meta-analyses. Concern about confounding by betel nut use is relevant to studies in Bangladeshi populations. There are no studies of Bangladeshi populations used in the bladder cancer meta-analysis. There is one study of Bangladeshi populations used in each meta-analysis for lung cancer, diabetes, and IHD. The degree to which each of these studies influenced the final modeling results for the respective dose-response meta-analyses is evaluated in the leave-one-out sensitivity analyses discussed in Section C.1.2. Interesting, in all cases, the exclusion of Bangladeshi studies that failed to control for betel nut consumption raised the pooled logistic slope parameter value by approximately 30%. Overall, this indicates that inclusion of Bangladeshi studies in the dose-response meta-analysis did not greatly influence the final pooled slope estimation and did not result in overestimates of risk.

[underlined: Public Comment:] One commenter (Exponent) noted that nutritional deficiencies are potential confounders of associations between inorganic arsenic and health outcomes because they influence arsenic toxicity through reduced methylation capacity and they also are independent risk factors for the same diseases that are investigated in the assessment, including bladder cancer, lung cancer, cardiovascular disease, and neurobehavioral effects. This commenter further noted that nutritional deficiencies are often more common in socioeconomically deprived populations with higher arsenic exposure.

[underlined: EPA Response:] The studies used in dose-response were considered to reasonably address potential confounding factors related to these nutritional deficiencies, including proxies such as BMI and SES. In addition, generally consistent results are observed across studies with or without potential confounding by nutritional deficiencies, including populations across different countries, which alleviates concern for potential confounding by nutritional deficiencies across the entire evidence base for each of the outcomes evaluated.

#### Study selection and dataset selection for dose-response analyses

[underlined: Public Comment:] One public commenter (Superfund Settlement Project and RCRA Corrective Action Project) found “The documentation and methods used to identify studies and data for inclusion in Bayesian meta-regression dose-response analyses are lacking in transparency. While the methods for study and data selection are presented in the Systematic Review Protocol (USEPA 2023c), it is impossible to follow the decision process through the Systematic Review (USEPA 2023a), Systematic Review Supplemental Data (USEPA 2023b), and the BMD data files.”

[underlined: EPA Response:] Section 4.3.1, “Identification of Studies and Data for Bladder Cancer, Lung Cancer, Diseases of the Circulatory System, and Diabetes dose-response meta-analyses,” has been updated and clarifications added to improve transparency. The public commenter also provided this comment under charge question 2.b.

[underlined: Public Comment:] Multiple commenters (Dr. Paolo Boffetta; The Pesticide Policy Coalition; National Cotton Council of America; Superfund Settlement Project and RCRA Corrective Action Project; USA Rice) provided comments on the use of epidemiological studies of high exposure populations. One commenter (Dr. Paolo Boffetta) stated that the inclusion of dose-response analyses of results based on categories at high (i.e., greater than 100 µg/L) is not appropriate since these results may bias the results of the dose-response relationships at low doses. This commenter recommended that dose-response analyses restricted to results at low exposure levels (greater than 50 µg/L to less than 100 µg/L) are not affected this bias. Three commenters (The Pesticide Policy Coalition; National Cotton Council of America; USA Rice) provided similar comments that epidemiologic studies are not representative of US populations and a fourth commenter [SSP&RCAP] noted that conclusions reached regarding low-dose findings can be very dependent upon the epidemiologic studies used to evaluate the dose-response in the low concentration region and identified several epidemiologic studies (Guo et al., 2007; Chiou et al., 2001; Lewis et al., 1999; Karagas et al., 2004; Lamm et al., 2004; Han et al., 2009; Baastrup et al., 2008) of low dose drinking water studies that evaluate cancer outcomes evaluated in the assessment that are not included in the dose-response meta-analysis.

[underlined: EPA Response:] While EPA focused its dose-response on studies with exposures ranging from US background levels to 100 μg/L in drinking water, more highly exposed groups were evaluated when those data were also available. This approach was supported during the 2019 NASEM review of the protocol (NASEM, 2019). Thus, the iAs assessment uses a wide set of epidemiologic studies in the dose-response of cancer and non-cancer outcomes, including studies of relatively low and high exposures. The endpoint-specific study selection tables (see Tables C-22, C-33, C-42, C-49, C-58, and C-59) show that many U.S. population studies are included in the study-specific analysis along with studies conducted in geographic locations that are reasonably expected to be representative of U.S. populations (i.e., Europe, Mexico, etc.) with respect to demographic factors and exposure levels. Specifically, 55%, 33%, 75%, and 40% of studies included in the bladder cancer, lung cancer, diabetes, and IHD meta-analyses (respectively) come from these US or US-like populations. Populations with higher exposure burdens are included in the meta-analyses (i.e., Bangladesh, Inner Mongolia, etc.) for lung cancer, diabetes, and IHD, but this is considered a strength in the analysis. Conducting meta-analyses across multiple, diverse populations allows for the inclusion of multiple populations of many different potentially susceptible sub-groups and exposure profiles. Further, inclusion of exposure levels greater than 100 µg/L is consistent with other published dose-response meta-analyses, including Shao et al. (2021) and Lynch et al. (2017b).

The study selection section describing which studies were considered for dose-response analyses and inclusion/exclusion criteria has been substantially clarified in the assessment (see Sections 4.3.1, 4.4, and 4.5). For each outcome considered for dose-response, the number and identity of studies that did not meet the study selection inclusion criteria are identified in the text and accompanying figures. Regarding the specific studies highlighted in this comment, they were excluded from the dose-response meta-analysis for a variety of reasons, including not being a case-control or cohort study, being conducted in southwest Taiwan, not reporting ORs or RRs, or not reporting responses for categorical dose groups.

[underlined: Public Comment:] One commenter (Exponent) noted that the draft assessment and appended protocol documents contain a considerable amount of information on EPA’s deliberations and recommended that the clarity of the overall assessment would be greatly improved by clearly presenting the specific analyses within the selected studies that were used in the cancer slope factor and reference dose derivations. This commenter further noted that epidemiological studies often present more than one analyses of the data based on different levels of adjustment for covariates or confounding factors, exposure metrics, participant characteristics, etc. and recommended that the rationale for the selection of specific analyses should also be clearly documented. One additional commenter [Superfund Settlement Project and RCRA Corrective Action Project] similarly indicated that to follow EPA’s decision process, more details are needed to understand and transparently document the EPA’s study-selection decision process and overall results in regard to studies that were selected for quantitative analysis.

[underlined: EPA Response:] The study selection section describing which studies were considered for dose-response analyses and inclusion/exclusion criteria has been substantially clarified in the assessment (see Sections 4.3.1, 4.4, and 4.5). For each outcome considered for dose-response, the number and identity of studies that fail to meet the study selection inclusion criteria are identified in the text and accompanying figures. For studies that present multiple analyses (i.e., either multiple dose-metrics or models that control for different sets of confounders) the specific analyses that were selected for dose-response are identified in the assessment text and/or tables. EPA prefers adjusted models that do not include independent covariates for factors that are not themselves exacerbated by arsenic exposure (see Section 4.3.1).

[underlined: Public Comment:] One commenter (Exponent) suggested that associations between recent or lifetime average arsenic exposures (water concentrations) and cancer risk in populations will underestimate historical exposures to high arsenic water concentrations before the advent of reductions in arsenic levels in the water supplies. This commenter noted that depending on which data sets EPA used in the dose response analyses, exposure may be underestimated thereby increasing the apparent risk per dose.

[underlined: EPA Response:] EPA is aware of the uncertainty in estimating the relevant lifetime dose for populations with very high sustained historical iAs exposures that were substantially mitigated at some point during the study population’s lifespan (e.g., studies conducted SW Taiwan). This is a factor that EPA considered when selecting studies for meta-analysis (see assessment Section 4.3.1 subsections that describe “Data Sets Selected” for each endpoint analyzed). The degree of uncertainty can vary considerably depending on the quality of historical records. For instance, studies of populations exposed via domestic wells with highly variable arsenic concentrations and few historic records are considered more uncertain (e.g., all SW Taiwan studies were excluded from the meta-analyses) than studies of populations with a single, public water supply with well documented historical arsenic drinking water concentrations (e.g., Chile studies that were included in the meta-analyses). See Section 4.3.1 for additional discussion of study uncertainties and exclusions.

[underlined: Public Comment:] One commenter (Exponent) noted that the population-based case control study by Baris et al. (2016) found no association for arsenic water concentration and bladder cancer but that higher self-reported intake of drinking water from all sources (not just well water) was associated with bladder cancer. This commenter warned that recall bias could affect reported drinking water intake rate estimates in case-control studies in which participants know their cancer status.

[underlined: EPA Response:] In Section C.1.2 of this Appendix, under “Bladder Cancer Sensitivity Analysis,” EPA describes the reasons consumption metrics are preferred over drinking water concentration as a dose metric from the Baris et al. (2016) study and why recall bias is not considered to be a major concern for the Baris et al. (2016) study. As mentioned in Section C.1.2, “in an attempt to address recall bias, Baris et al. (2016) asked study participants if they ‘made a major change in their total water intake during their adult life.’ When people that had made such a change were excluded from the analysis, the odds ratios by water intake were not substantially different than those for all participants.” A further discussion of the considerations taken by authors to address recall bias is included in C.1.2. The HAWC study evaluation judgement for Baris et al. (2016) has been expanded to include consideration of recall bias.

[underlined: Public Comment:] One commenter (Exponent) suggested that the epidemiologic studies used for RfD derivation for cardiovascular disease incidence and/or ischemic heart disease incidence (Wade et al., 2015; Moon et al., 2013; James et al., 2015; Chen et al., 2013) had high risk of bias because of serious limitations for representing inorganic arsenic exposure and dose-response at low doses. Specifically, this commenter expressed concern that reference doses were biased towards overestimation of risk because of several factors: the epidemiologic studies were conducted in susceptible populations not representative of the United States general population, underestimation of exposure, sampling error in the James et al. (2015) study, and use of creatinine-adjusted urine concentrations in low-creatinine populations.

[underlined: EPA Response:] Derivation of a reference dose includes consideration of sensitive subgroups (see IRIS Glossary at https://www.epa.gov/iris/iris-glossary#tab1). Ideally, to adequately characterize risks in sensitive subgroups when considering study attributes for the evaluation of studies for derivation of toxicity values, studies that provide risk estimates in the most susceptible groups are preferred (U.S. EPA, 2002b, 2005a, b, 2012). Thus, deriving candidate values and the ultimate reference dose for inorganic arsenic via a dose-response meta-analysis that incorporates studies conducted in sensitive/susceptible populations reflects application of EPA human health guidelines All four studies identified in this comment were determined to be high or medium confidence studies after risk of bias study evaluation;^44^ no domains in any of these studies were determined to have “definitely high risk of bias.” Overall, potential domain-specific limitations were balanced by other strengths of the study across other domains. Study evaluations are holistic judgments based on all domains that are considered. A judgment of “probably high risk of bias” in one domain does not necessarily mean that the entire study is low confidence or unsuitable for dose-response. Regarding use of creatinine-adjusted urine concentrations in low-creatinine populations, see responses above under “Creatinine adjustment and other aspects of interpreting urinary arsenic studies.”

[underlined: Public Comment:] One commenter (Exponent) raised additional concerns over the use of the Moon et al. (2013) study. This commenter stated that the less adjusted model for CVD and IHD incidence used by EPA had higher reported risks and these associations were attenuated and not statistically significant after adjustment for hypertension, diabetes, and albuminuria. Additionally, this commenter stated that lack of creatinine adjustment in the Kuo et al. (2022) study resulted in statistically insignificant inverse associations between speciated urinary arsenic and CVD mortality and that exposure misclassification = lack of creatinine adjustment (and bias to the null) is not expected to reverse the direction of association (i.e., change an inverse association to a positive one).

[underlined: EPA Response:] EPA’s rationale for selecting model 2 from Moon et al. (2013) is noted in footnotes in Section 4.3.1 of the main assessment and in Table C-50. The more adjusted models in Moon et al. (2013) (Models 3 and 4) controlled for hypertension and diabetes. These models are not preferred because hypertension and diabetes are possibly on the causal pathway between arsenic exposure and CVD and IHD. This is also discussed in Moon et al. (2013). EPA prefers adjusted models that do not include covariates that are themselves exacerbated by arsenic exposure (see Section 4.3.1).

Regarding the findings of Kuo et al. (2022) study, the study authors note in their discussion that not using any urine concentration correction resulted in misclassification and null associations. As the commenter points out, results from models without creatinine adjustment are inverse, straddle the null, and do not provide strong evidence of arsenic’s impact on cardiovascular disease mortality. However, results from models that include urine concentration correction (see Table 2, Models 1-4) indicate that elevated ∑As (iAs + methylated species) was associated with higher adjusted hazards ratios for CVD mortality. EPA notes that while misclassification resulting in bias to the null is a common heuristic in epidemiology, it may not always be the case: alternative patterns in the data, including bias away from the null, have the potential to be observed (Yland et al., 2022). Similarly, as stated by Whitcomb & Naimi, “error in a study is not the same as bias as a tendency across studies, and there is no guarantee that an estimate from a study affected by nondifferential misclassification of exposure will be an underestimate” (Whitcomb and Naimi, 2020). In other words, according to the common heuristic, one reason that the Kuo et al. (2022) study appears null and inverse may be because it underestimates the true statistically significant inverse estimate. Alternatively, because the heuristic does not always hold in an observed sample, the effect estimate may be impacted by some uncertain error term, making it difficult to predict the true value of the effect. For additional discussion on urinary concentration correction methods, see Section 1.6.2 and responses above under “Creatinine adjustment and other aspects of interpreting urinary arsenic studies”).

[underlined: Public Comment:] One commenter (Superfund Settlement Project and RCRA Corrective Action Project) stated that it appeared the assessment grouped type 1 and type 2 diabetes studies together in the dose-response analysis, citing this as another example of aggregation bias.

[underlined: EPA Response:] EPA agrees with the commentor, However, the dose-response meta-analysis of diabetes in the external peer review draft did not include studies of type 1 diabetes. The vast majority of arsenic studies focus on type 2 diabetes and no studies of type 1 diabetes advanced to the point of consideration for dose-response. For clarity, studies of type 1 diabetes are explicitly indicated as excluded in the revised assessment (see Section 1.6.5 for details).

#### Dose conversions and estimation of background arsenic exposure levels

[underlined: Public Comment:] One commenter (Exponent) noted that in foreign subsistence populations, average drinking water intake is greater than in the United States because of factors such as warm climates, outdoor labor, and less access to store purchased beverages. This commenter further notes that arsenic exposures from total intake of contaminated well water is also increased by use of the water to grow and process local vegetables and rice, and thus the total among of arsenic intake in these populations will be underestimated by surveys of direct drinking water intake.

[underlined: EPA Response:] As part of the dose conversion process, EPA incorporates information on population-specific water consumption rates and dietary exposures to arsenic. In this way, any extra water consumption of subsistence populations is explicitly accounted for in EPA’s calculations of daily intake values across exposure groups (see Section C.1.1; Treatment of Dose Uncertainty). However, these studies do not provide data that would allow EPA to estimate how dietary exposures within a population might change across the reported drinking water exposure groups. Consequently, EPA assumes that population-specific dietary intake is constant across exposure groups. EPA acknowledges that increased dietary exposure might accompany increased drinking water exposure for populations that survive mainly off crops that are nourished by the same water as they drink and that do not have alternative (e.g., store purchased) sources of beverages. For urinary biomarker studies, EPA assumes that the level of urinary tAs represent an integrated estimate of iAs exposure from both drinking water and dietary sources. Therefore, no assumption is necessary when using exposure as characterized by these studies because, if dietary exposures differ across dose-groups, the measure of total urinary arsenic would capture those differences. This means that when using urinary arsenic studies, increased dietary exposure is explicitly accounted for in the measurement of the urinary tAs concentrations, if dietary exposures do differ across dose groups.

[underlined: Public Comment:] One commenter (Superfund Settlement Project and RCRA Corrective Action Project) asked what the justification was for transforming published iAs exposure categories into a continuous measure given the “significant discrepancy in statistically significant outcomes between various studies.” This commenter noted that many studies in the bladder cancer dose-response meta-analysis had non-statistically significant responses at low doses.

[underlined: EPA Response:] The dose-response methods used in the iAs assessment do not “[transform] published iAs exposure categories into a continuous variable..” Rather, different individual study dose-metrics are converted into a unified dose-dose metric, while retaining the categorical exposure groups within each individual study. With respect to the comment on bladder cancer studies, it is true that studies included in the meta-analyses for all outcomes included dose groups without statistically significant responses. However, one of the main benefits of meta-analyses is the pooling of dose-response data across multiple studies, some of which may show effects doses other studies do not.

[underlined: Public Comment:] One commenter (Electric Power Research Institute) noted that every study is reported as a dose exposure range, and that, appreciating that the methodology for handling dose ranges is provided, it was unclear how reliable it is to convert data from studies with ranges into a single cut-off.

[underlined: EPA Response:] Section C.1.1 discusses the methodology the assessment used to estimate single dose values from study reported dose ranges. The approaches used by EPA are more sophisticated than methods used in prior meta-analyses. Previous meta-analyses published in the literature have simply taken the mid-point of a range as the single dose/exposure value to use in a dose-response analysis. EPA has instead used a maximum likelihood estimation (MLE) approach to calculate the mean exposure value within each exposure-range, based on the proportions of study participants in each exposure range category. Additionally, to account for the fact that studies typically report an open-ended range for the high exposure category, EPA has used the same likelihood approach but has calculated the profile likelihood upper and lower bounds on the MLE to generate “high-end” and “low-end” estimates of mean exposure for the high exposure group. While the MLE estimates of exposure are used in the main dose-response meta-analysis, outcome-specific sensitivity analyses are included in the assessment to judge the impact they have on modeling results.

[underlined: Public Comment:] One commenter (Simplot) provided numerous comments on the approach EPA used to define the average background U.S. exposure level to iAs. First, this commenter noted that EPA assumes a background dietary dose of 0.02 μg/kg-day from Xue et al. (2010) in performing its dose-response modeling, which corresponds to the “all age groups” median exposure. This commenter suggested that a more typical approach when presenting information about the background rate of intake of a substance is to present the average amount, not the median amount. This commenter recommended the mean value reported by Xue et al. (2010), 0.05 μg/kg-day, be used to represent the background iAs intake rate, thus matching mean exposure to mean cancer incidence rates.

The commenter also noted that EPA cites Mendez et al. (2017) and EPA’s Exposure Factors Handbook (U.S. EPA, 2019) for its drinking water US background rate of 0.0165 μg/kg-day, based on a reported 1.5 μg/L as the median arsenic county mean concentrations from USGS drinking water data from the 1980s and 1990. This commenter notes that this assumed value of 1.5 μg/L contradicts the value listed in Section 1.5 of the USEPA’s 2023 Draft Toxicological Review where it is stated that the average level in drinking water is 2 μg/L with “12% of the water supply from surface water in central portions of the U.S. and 12% of groundwater sources in western portions of the U.S. exceeding 20 μg/L.” This reviewer ultimately concludes that 1.5 μg/L as an estimate of the national background level of arsenic in drinking water is biased low.

Regarding the applied water consumption rate, this commenter criticized EPA’s use of a national average water intake level of 0.011 L/kg-day for all ages from Table 3-1 in EPA Exposure Factors Handbook (U.S. EPA, 2019), pointing out that the 0.011 L/kg-day value was taken from a NHANES 2-day recall data for tap water only. This commenter stated the assumed background intake level is biased low because it ignores water consumed from purchased drinks, such as sodas, juices, alcoholic beverages, etc., all of which contain low levels of arsenic. This reviewer suggests that EPA has ignored its own guidance regarding the amount of drinking water consumed and that for decades USEPA’s drinking water program has assumed that 10 kg children and 70 kg adults consume drinking water at the level of 1 L/day and 2 L/day, respectively (USEPA, 2018).

This commenter also criticized the assessment for proposing dose-response values for iAs that have ignored the background dose obtained from soil via dermal contact and incidental ingestion from hand-to-mouth activities. This commenter notes that Section 1.5.1 of the assessment states “[n]aturally occurring levels of inorganic arsenic in soil are approximately 5 mg/kg but can range from 1 mg/kg to 40 mg/kg…” and that a value of 5 mg/kg inorganic arsenic in soil corresponds to 0.011 µg/kg-day inorganic arsenic exposure using EPA CERCLA guidelines for dermal contact and incidental soil ingestion.

Lastly, this commenter noted that EPA’s assumed background exposure of 0.0365 µg/kg-day inorganic arsenic is lower than doses that it used to model referent groups in US-based epidemiological studies.

[underlined: EPA Response:] In deriving the background estimate of exposure, EPA used the median dietary estimate from Xue et al. (2010) of 0.02 μg/kg-day in conjunction with median drinking water level estimate obtained from Mendez et al. (2017) of 1.5 μg/kg. The median as an estimate of the central tendency is preferred when data are skewed as it is more resistant to outliers than the mean. Given that the mean estimate of dietary exposure from Xue et al. (2010) is 0.05 μg/kg-day, it clear that the dietary estimates reported in Xue et al. (2010) are right-skewed. Therefore, the use of the median dietary and median drinking water concentrations are retained in the final assessment and the estimated background exposure of 0.0365 μg/kg-day iAs is used in all lifetable and benchmark dose calculations. Also, mean cancer rates are not used in the assessment. Rather, age-stratified incidence data is used for bladder cancer and lung cancer and from these stratified data, the lifetime probabilities of these diseases are calculated and used in subsequent lifetable calculations.

EPA disagrees that the background exposure level is biased low specifically because it ignores water consumed from purchased beverages. Consumption of purchased drinks, such as sodas, juices, and alcoholic beverages are included in the median dietary estimate of 0.02 μg/kg-day provided by Xue et al. (2010). Regarding the use of a water consumption rate of 0.11 L/kg-day, the EPA Exposure Factors Handbook has been iteratively updated and the water consumption rate estimate (which averages across children and adults) provided in the 2019 update is the most recent U.S. drinking water consumption rate estimate available.

Soil ingestion is not expected to be a major route of exposure for inorganic arsenic. Given a mean soil concentration of 5 mg/kg soil and a soil + dust ingestion rate of 30 mg soil/day (as recommended by Table 5-1(adults) the most recent Exposure Factors Handbook), daily intake of arsenic from contaminated soils would only be 0.002 μg/kg-day. This is less than 6% of the background inorganic arsenic exposure estimated for the drinking water and dietary routes of exposure. While dermal exposures to inorganic arsenic can occur, it is not considered a primary route of exposure (ATSDR, 2007), limited primarily to specific occupational situations (Xue et al., 2010; Ahmed et al., 2019; IARC, 2004a), and thus is not likely to contribute substantially to the overall background levels of exposure for the general public. For example, using a reported soil concentration of 5 mg/kg soil and parameters consistent with an assumed lifetime general population (i.e., residential) exposure (see Exhibit 3-5 (U.S. EPA, 2004), the estimated daily intake from dermal exposure to inorganic arsenic is estimated to be only 0.0001 μg/kg-day. This is only approximately 0.27% of the background inorganic arsenic exposure estimated for the drinking water and dietary routes of exposure. Dermal exposure to inorganic arsenic from bathing and/or showering is not expected to be a major route of exposure and analyses have shown that bathing behavior in children is not associated with urinary arsenic levels (Smith et al., 2016), confirming this expectation. Ultimately, the SAB (SAB, 2024) agreed with EPA’s approach to estimate background levels based on central estimates of dietary and water intake. However, acknowledging that there is uncertainty in the estimation of the U.S. background iAs exposure level, a sensitivity analysis has been added to the assessment in which a “high-end” estimate of background exposure is used in the lifetable calculations (see endpoint-specific sensitivity analysis results in Section C.1.2). The results of this sensitivity analysis show that assuming a higher background exposure level of 0.11 µg/kg-day does not decrease estimated mean lifetime extra risks by more than 5% for any modeled endpoint.

Regarding the comparison of the assumed average background exposure for the entire general U.S. population and referent group exposures in individual U.S. study populations, it should not be surprising that some studies had lower referent group exposures levels. If the assumed background exposure level is an accurate estimation of the true central estimate of the background exposure level, then one would expect that one-half of the U.S. general population to have higher exposures compared to background and half to conversely have lower exposures.

[underlined: Public Comment:] One commenter (Students of Johns Hopkins Bloomberg School of Public Health Risk Sciences and Public Policy Institute) noted that specific populations may have different dietary exposure to arsenic and that because EPA chose to use studies outside of the United States, not all the dietary exposure results are able to be extrapolated to US populations.

[underlined: EPA Response:] Regarding dietary exposures, population-specific dietary exposure data were used to conduct study-specific dose conversions whereas an average estimate of the central tendency of US dietary exposure was used for the lifetable and RfD calculations. Therefore, no concerns should exist regarding the generalizability of dietary exposures.

[underlined: Public Comment:] One commenter (Electric Power Research Institute) requested that the process for adjusting dose using conversions that required distributions that represent individual or population-level variability in each factor be more thoroughly documented. This commenter also noted some conversion factors (e.g., CE and f) that are included in the conversion formula are missing from exposure factor tables in the Supplemental Materials. Another commenter [ASTF] commended EPA for explicitly considering the uncertainty of the exposure estimates using a Monte Carlo approach. They stated that “Given the uncertainty in exposure characterization and its effect on iAs potency estimates, the approaches taken by US FDA (2016) and US EPA (2023a) are important refinements to previous assessments.” However, this commenter did not feel that the variability of dietary iAs exposure was adequately accounted for when estimating background exposures.

[underlined: EPA Response:] The revised assessment documentation includes dose-conversion worksheets, along with a conversion factor validation spreadsheet. All conversion factors have been defined. EPA appreciates the encouragement from the commenters regarding the characterization of exposure uncertainty. With respect to background exposures, the method by which EPA converts study specific exposure metrics to the unified daily intake exposure metric specifically accounts for dietary exposure. In brief, all exposure factors that are used to do the dose conversions are assumed to come from a distribution of values and this distribution is randomly sampled when doing the conversions (see Section C.1.1: Treatment of Dose Uncertainty: Dose-Conversion Method Overview for details on how dose conversions were carried out in the assessment). Therefore, the variability in the dietary exposure for study participants is explicitly accounted for in the dose conversion methodology.

#### Dose-response methods

[underlined: Public Comment:] Three commenters [Superfund Settlement Project and RCRA Corrective Action Project; Electric Power Research Institute) provided comments on the methods EPA used to calculate the effective counts for dose-response. Specifically, these commenters noted that the approach used by EPA constrains the confidence intervals so that they match the reported adjusted results, and that this method differs from Greenland and Longnecker (1992). These commenters raised concerns that the method in the iAs assessment ignores potential issues with the referent group that can arise in categorial analysis of case-controls studies and recommended that EPA perform a sensitivity analysis to see if currently effective count adjustment differs greatly from that described by Greenland and Longnecker (1992), as well as making a comparison to a conventional dose-response that evaluates dose-response data from the highest quality study. Additionally, one of these reviewers requested clarification on the statement that “[t]he Bayesian analysis perspective also influenced our choices” [of constraints]. One commenter (Electric Power Research Institute) specifically recommended it would be helpful to have the methods/algebra for calculating the counts of affected and nonaffected individuals more explicitly provided in the assessment. This commenter also commented that it was not clear how the calculation of effective counts contributed towards adjusting for covariates and that a side-to-side comparison of control and case population demographics would be informative.

[underlined: EPA Response:] The case-control studies from which the dose-response data were obtained typically report comparisons of case and control demographics and other variables the authors considered relevant for adjusting OR estimates. In fact, it is exactly those adjustments that the effective count calculations are intended to reflect, i.e., the effective counts yield values that entail ORs and confidence limits that match the adjusted ORs and confidence limits reported by the original investigators. As such they inherently adjust for covariates, in a manner consistent with the approaches used by the original investigators. The rationale for the method used to calculate effective counts is extensively discussed in Section C.1.1., including a discussion of and rationale for the constraints used in the method.

A comparison to a single-study dose-response approach is not included in the revised assessment given the use of meta-analysis methods are the focus of the assessment, a decision supported by NASEM during the review of the iAs Protocol and mirrored in the SAB panel report. Specifically, regarding the estimation of effective counts, The SAB panel supported EPA’s approach, stating “[t]he panel agreed that the method was scientifically justified…”

The full methodology for calculating the effective counts for cohort and case-control studies is provided in Section C.1.1, which includes a full discussion of how the effective count methodology retains the control for confounding conducted in individual studies. Information on control and case demographics is available in the individual studies used for dose-response and EPA has not included this information in the assessment.

[underlined: Public Comment:] One commenter (Dr. Kan Shao) objected to the use of the logistic dose-response model as the most appropriate model for the dose-response analyses. This commenter objected to the characterization of the logistic model as “flexible and non-linear,” stating that the logistic model is a two-parameter model and is thus not a flexible model. Further, this commenter notes that the assessment appendix describes the logistic model as “simple, monotonic.” This commenter suggested that commonly used models, such as the Probit, and C-loglog model, which have similar structure as the logistic model, can be employed. Further, this commenter and an additional commenter (Electric Power Research Institute) also claimed that no justification was provided on why only two non-monotonic dose-response models (i.e., the fractional polynomial [FP] and double Hill [DH] models) were selected for the sensitivity analysis investigating the assumption of monotonicity. One of these commenters (Dr. Kan Shao) additionally noted that some parameters in the FP and DH models were limited to reduce complexity and suggested that if a non-monotonic curve was necessary, the dichotomous Multistage model could be used without necessity for restricting model parameters. This commenter lastly noted that the FP and DH models are not commonly used in benchmark dose modeling.

[underlined: EPA Response:] The logistic model was used by EPA to specifically allow for the modeling of cohort and case-control studies together in a unified dose-response meta-analysis, an approach supported by the SAB and NASEM.

Specifically, the logistic model was used in dose-response modeling because its use allows for the estimation of the prospective likelihood for case-controls studies, and thus their inclusion in a dose-response meta-analysis along with cohort studies without making simplifying assumptions e.g., the rare disease assumption that RR ∼OR for diseases with low prevalence. If a non-logistic model were to be used (e.g., Multistage, Probit, C-loglog), the RR∼OR assumption would be needed and this assumption violates the observed high prevalence that the modelled non-cancer outcomes (ischemic heart disease, diabetes) have in the US general population. However, acknowledging the benefits of fitting more flexible model(s) to the epidemiologic data, EPA has applied an extension of the logistic model (i.e., the “logistic-power”) in the main dose-response analysis of the revised assessment. The rationale and justification for using the logistic (and logistic power) model can be found in Section C.1.1. Also note that the fractional polynomial models that were included as sensitivity analyses include versions that might be characterized as multistage models within the general logistic model framework. Thus, EPA has, in essence, considered several other model forms, but has done so in a manner that allows the integrated analysis of cohort and case-control studies.

With respect to qualitative descriptions of the logistic model related to its complexity, it should be noted that neither description of the logistic model that the commenter objected to (i.e., “flexible and non-linear,” “simple, monotone”) is incorrect and the objections to its characterization are largely semantic. It is factually correct to describe the logistic model as non-linear, and compared to a linear model, the logistic model is indeed “flexible.” This commenter themself note that the “… logistic model can illustrate a full “S” shape curve like more complicated models….” Further, in the context of the appendix material cited by this commenter, which is a comparative description of the logistic model to the FP and DH models, it is accurate to describe the logistic model as “simple” compared to these very flexible models. Regardless, concerns over the logistic model not being a flexible model given it is a two-parameter model are obviated in the revised assessment as the logistic-power model (a three-parameter model) now serves as the basis for all dose-response analyses in the assessment. It is also worth noting that the logistic model has been used to describe a distribution of thresholds in a population, and in that sense can itself be considered a threshold model (Prentice, 1976).

When conducting the sensitivity analysis on whether non-monotonicity needs to be accounted for in the dose-response analysis, extensions of the logistic model were used. The external peer review draft of the assessment already contained a justification for the use of these models, and this discussion is retained in the revised draft and is also located in Section C.1.1 (see Sensitivity Analysis of Possible Non-Monotonic Dose-Response Relationships). As to the question of why only two non-monotonic models were used in the assessment, EPA, 39 variations of these two models were used (given different specifications of their parameters). EPA considers a sensitivity analysis investigating the behavior of 39 alternative models more than sufficient to investigate the possibility of non-monotonicity in the dose-response relationship.

[underlined: Public Comment:] One commenter (Dr. Kan Shao) criticized the comparison and selection criteria among the logistic, FP, and DH models, calling them biased, not clear, and subjective. This commenter stated that, given the dose-response meta-analysis approach is relatively new, it is important to develop an objective approach, preferably based on well accepted statistics, to compare models rather than using subjective criteria to select a model. This commenter also noted that the reference background dose used in the main assessment dose-response and the sensitivity analysis of non-monotonic dose-response shapes differs. This commenter further criticized the sensitivity analysis using the FP and DH models because it was not in compliance with BMD Technical Guidance and recommended that the approach requires extensive peer review and evaluation.

[underlined: EPA Response:] EPA does not agree that subjective criteria were used. In fact, the commenter references the section of the appendix that describes the parameterization of all the FP models, specifically the definition of the prior distribution for the parameter that describes the expected OR at low doses (to prevent estimation of infinite odds ratios as dose approaches zero). The commenter appears to be confusing selection of model priors (an inherently subjective exercise) with selection of models (i.e., objective selection of the “best” model). Second, the commenter notes that “unreasonable shapes of dose-response curves (e.g., the one shown in Figure C-3) were based on some specific values of the parameters.” The cited figure presents a non-monotonic curve. Given the entire point of the sensitivity analysis is to investigate the possibility of non-monotonicity, EPA finds it curious to call out a non-monotonic curve as unreasonable. Regarding this commenter’s suggestion that the assessment apply objective criteria to compare models, the external peer review draft described the possible use of two approaches based on maximum posterior likelihood or average posterior likelihood and provides these statistics for all three models under consideration (logistic, FP, DH). The sensitivity analysis investigating non-monotonic dose response shapes with the FP and DH models was conducted at a time when a different background dose was being used in the main assessment. While comparisons between the sensitivity analysis (using the logistic, FP, and DH models) is not comparable to the main assessment analysis (using the logistic power model), given the different background doses, the internal comparability and conclusions of the sensitivity analysis are still valid.

EPA’s Benchmark Dose Technical Guidance (U.S. EPA, 2012) states in its Introduction that it “… should not be viewed as precluding research that will improve quantitative risk assessment.” Given that statement, the fact that the models used in this sensitivity analysis are not mentioned in the BMD Technical Guidance or that model evaluation criteria used in the present analysis differ from those outlined in the BMD Technical Guidance should not be used to question the utility or validity of sensitivity analysis. Regarding the need for peer review, EPA agrees and recognizes that the peer review provided by the Scientific Advisory Board meets the definition of “extensive peer review and evaluation.” In fact, regarding the sensitivity analyses of the monotonicity assumption, the SAB panel “… commended the EPA in those explorations ….”

Acknowledging that the section describing the sensitivity analysis using the FP and DH models presents very technical modeling discussions, it has been revised in the draft assessment to ensure clarity and transparency in presenting results and the ultimate conclusion of the sensitivity analysis.

[underlined: Public Comment:] Two commenters (Superfund Settlement Project and RCRA Corrective Action Project; Electric Power Research Institute) requested more details on the specific inputs used the dose-response meta-analysis, including requests for variable definitions. One commenter (Superfund Settlement Project and RCRA Corrective Action Project) also noted discrepancies in some output tables in the dose-response appendix.

[underlined: EPA Response:] EPA has expanded documentation of the inputs and outputs of the dose-response meta-analysis included in the modeling results files, including providing a structured workflow document with the dose-response documentation, mapping to all input and files and including an extensive variable dictionary for lifetable analyses. A non-technical ‘primer’ explaining the analysis (dose-response meta-analysis and lifetable) has additionally been added to Section C.1.1. Additionally, the revised modeling appendix has been cross-checked to ensure that all reported modeling results presented in tabular format accurately reflect the outputs obtained from the modeling software.

[underlined: Public Comment:] One commenter (Superfund Settlement Project and RCRA Corrective Action Project) described the dose-response model used in the dose-response meta-analysis as a multiplicative exponential model that is mathematically incapable of describing the threshold dose-response expected for inorganic arsenic carcinogenicity and that the model would tend to force the dose-response at low doses to appear linear. These two commenters state that the dose-response meta-analysis is not scientifically justified. These two commenters recommended the use of the Hill model in the assessment, as done in Shao et al. (2021).

[underlined: EPA Response:] The model used in EPA’s dose-response meta-analysis is a logistic model. Regarding the claim that the logistic model cannot describe a threshold dose-response shape, the NASEM report on the iAs Protocol (NASEM, 2019) points out that “… the logistic model is a member of a class of dose-response models known as tolerance distribution models. Tolerance distribution models assume that each organism has a latent tolerance to a chemical and an adverse response only occurs once this threshold is exceeded. The logistic regression model assumes that the distribution of these latent tolerances is logistic and uses the cumulative distribution function to calculate the probability that tolerance is less than a given dose. Thus, assuming a positive dose-response and a low background rate, the logistic regression model will produce an S-shaped curve with the left-hand tail approaching a threshold of zero extra response, if not exactly so.” This description is consistent with the response above noting that the logistic model has been used to describe a distribution of thresholds in a population, and in that sense can itself be considered a threshold model (Prentice, 1976). Therefore, if a threshold is evident the data being modeled, the logistic model should be able to describe that behavior.

Regardless, in the interest of applying sufficiently flexible model(s) to the epidemiologic data being modeled, EPA has applied an extension of the logistic model (e.g., the “logistic-power”) in the main dose-response analysis in the revised assessment (see Sections 4.3.5 and C.1.1: Bayesian Dose-Response Meta-Analysis Methods for description).

[underlined: Public Comment:] Two commenters (Superfund Settlement Project and RCRA Corrective Action Project; Electric Power Research Institute) recommended that the assessment should discuss general issues with meta-regressions, including aggregation bias.

[underlined: EPA Response:] A non-technical ‘primer’ explaining the analysis has been developed (see Sections 4.3.5 and C.1.1: Bayesian Dose-Response Meta-Analysis Methods: Overall Summary of Hierarchical Bayesian Dose-Response Modeling and Lifetable Methods). More extensive discussion of core dose-response meta-analysis statistical concepts is outside the scope of the assessment.

[underlined: Public Comment:] One commenter (Superfund Settlement Project and RCRA Corrective Action Project) noted that the assessment contains many references to Allen et al. (2020b) and Allen et al.(2020a) for further descriptions of the methods. The commenter suggested that the methods should be specifically stated in the documentation of the assessment. The commenter further recommended that input and output files for the dose-response modeling be provided to the readers of the assessment.

[underlined: EPA Response:] In addition to citing the Allen et al. (2020b) and Allen et al.(2020a) publications, the assessment extensively points readers to the dose response modeling appendix containing a detailed description of the dose-response methodology and modeling results presented in tabular and graphical formats. For the revised assessment, EPA has expanded documentation of the inputs and outputs of the dose-response meta-analysis, including a structured workflow document with mapping to all input and files, an exhaustive variable dictionary, and a non-technical ‘primer’ explaining the analysis (dose-response meta-analysis and lifetable) and calculations therein (see Section C.1.1: Bayesian Dose-Response Meta-Analysis Methods: Overall Summary of Hierarchical Bayesian Dose-Response Modeling and Lifetable Methods).

[underlined: Public Comment:] One commenter (Exponent) provided a comment that modeling the full range of the dose response data using a model for which the shape of the low dose region is influenced by the high-dose data is a factor that inflates the calculated cancer slope factor and that upper bound estimates are even more affected by the high dose data than the maximum likelihood estimate.

[underlined: EPA Response:] Modeling the full range of the dose-response data is a standard practice in IRIS dose-response assessments as is using the upper bound estimates to calculate cancer slope factors.

[underlined: Public Comment:] One commenter (Electric Power Research Institute) pointed out limitations in the overall documentation of the assessment. Specifically, this reviewer recommended that documentation of the quantitative analyses could benefit from improved organization and explanation, as the methods used in the quantitative analyses are not sufficiently transparent nor explained well enough for an expert in the field to reproduce the results. For transparency, this commenter recommends that all input and output files associated with the modeling be provided as supplemental material.

[underlined: EPA Response:] The dose-response chapter of the assessment has been revised to more clearly present the results of the dose-response analyses. EPA has provided additional documentation in the modeling results files of the inputs and outputs of the dose-response meta-analysis, including a structured workflow document with mapping to all input and files) and an exhaustive variable dictionary, and a non-technical ‘primer’ explaining the analysis (dose-response meta-analysis and lifetable) and calculations therein (see Section C.1.1: Bayesian Dose-Response Meta-Analysis Methods: Overall Summary of Hierarchical Bayesian Dose-Response Modeling and Lifetable Methods).

[underlined: Public Comment:] One commenter (Simplot) requested that scatter plots showing the fit of the final pooled meta-regression dose-response models to the full data set of epidemiologic studies be provided in the revised assessment.

[underlined: EPA Response:] Dose-response curves to the individual studies were provided in the external peer review draft of the iAs assessment; in the revised assessment dose-response curves for the pooled analysis have also been provided (see endpoint-specific modeling results in Section C.1.2).

#### Mode-of-action and dose-response

[underlined: Public Comment:] Multiple commenters (Superfund Settlement Project and RCRA Corrective Action Project; Electric Power Research Institute; Dr. Samuel M. Cohen; Exponent; European Arsenic Consortium) claim that EPA did not properly assess the mode of action for the toxicity and carcinogenicity of iAs before determining the adequacy of the arsenic epidemiological evidence to characterize the dose-response. Two reviewers (Superfund Settlement Project and RCRA Corrective Action Project; Electric Power Research Institute) state the only valid approach for determining the low dose behavior of the carcinogenic effects iAs observed in epidemiologic studies is the consideration of dose-response data from in vitro studies with human cells. They assert there is strong evidence from mechanistic studies that arsenic is not mutagenic and that the dose-response relationship for carcinogenicity is highly nonlinear due to its association with chemical interactions with thiols in key cellular signaling proteins that disrupt control of oxidative stress, inflammation, DNA repair and replication with a threshold for carcinogenicity from drinking water exposures on the order of 20–50 ppb (Gentry et al., 2014b; Tsuji et al., 2019). These commenters criticized EPA for only citing one mechanistic study related to the inherent biological dose-response relationship of iAs (Clewell et al., 2007). They state that this publication was an early progress report that served as the basis for further studies, which have since been published, but were not considered in the assessment (Kenyon et al., 2008; Gentry et al., 2010, Clewell et al., 2011; Yager et al., 2013; Gentry et al., 2014b; Gentry et al., 2014a; Efremenko et al., 2015; Clewell et al., 2018; Efremenko et al., 2021). Another commenter (Exponent) noted that the IRIS assessment of iAs provides a unique opportunity for EPA to use evidence integration approaches to the fullest extent with the availability of multiple human epidemiology, animal, and mechanistic studies and that the use of any one of these data streams in isolation has serious limitations. This commenter contends that the available epidemiological studies are not well designed to characterize the low end of the dose response curve or identify no-adverse-effect levels and note that NASEM (2019) commented that mode-of-action analysis is particularly useful in understanding the relationship between exposure to a chemical and its biological outcomes at the low end of the dose-response curve. Two commenters (Dr. Samuel M. Cohen; European Arsenic Consortium) expressed concern over EPA’s reliance on epidemiology data to model responses at low exposure levels. They state that since there are no epidemiological data specifically for responses at the low exposure levels, the assessment used modeling to estimate response at those levels of exposure and recommends that modeling of the dose-response relationship should be done only after the shape of the curve is informed by mode of action, including an analysis of in vitro data.

[underlined: EPA Response:] The commenters suggestion that EPA did not carefully consider mode/mechanism of action information and only cited one mechanistic study related to the biological dose response (Clewell et al., 2007) is misleading and incorrect. Appendix A of the Systematic Review Protocol for the Inorganic Arsenic assessment describes analyses of modes of action common to multiple health effects. The appendix describes the analyses conducted by EPA to characterize MOAs associated with arsenic exposure, focusing on MOAs common to multiple adverse health effects versus tissue-specific descriptions. EPA considered over 5700 studies in these analyses, including all but four the references cited above (Miller et al., 2013; Kenyon et al., 2008; Efremenko et al., 2015; Efremenko et al., 2021). These references were not included for various reasons, such as: 1) they did not include original data (reviews) (Miller et al., 2013) 2) ADME studies without mechanistic information (Kenyon et al., 2008); 3) did not meet PECO criteria (mixtures study) (Efremenko et al., 2015), or 4) was published past the date of studies included in the MOA analyses in Appendix A (Efremenko et al., 2021).

EPA’s analyses presented in Appendix A of the Systematic Review Protocol for the Inorganic Arsenic revealed that the recognized MOAs for any of the hypothesized bases for inorganic arsenic (iAs)-induced disease are incomplete, poorly populated with key events, and/or nonspecific. This prevents a critical evaluation of dose-response relationships, particularly in the low-dose region. The following information from the 2019 Systematic Review Protocol (see Section 2.3.2.) summarizes consideration of MOA and mechanistic data to inform dose-response:

With respect to using MOA and mechanistic data to inform dose-response, EPA conducted a significant number of analyses of mechanistic information (see Appendix A), and a case study using idiopathic bladder cancer was undertaken to address the feasibility of using this information to inform dose–response modeling with respect to the shape of the curve, particularly in the low-dose region. Idiopathic bladder cancer was selected for the case study given the abundance of mechanistic data available for use in conducting the MOA analysis. The results of the literature review presented in Appendix A and case study were interpreted in the context of whether these analyses provided a firmer basis for reaching conclusions about the shape of the dose-response curve in the low-dose region compared with using the multiple epidemiological studies available that directly assess the effects of low-dose arsenic exposures in various U.S. populations. Ultimately, the MOA analyses were not considered more suitable than the epidemiological studies. This reliance on the epidemiological studies for use in dose-response analysis is similar to the recent meta-regression analysis of arsenic epidemiology studies conducted by TCEQ (2017) and Lynch et al. (2017b, 2017a), and is consistent with the focus on epidemiology studies in earlier assessments (EFSA, 2009; RIVM, 2001; FDA, 2005; Health Canada, 2006; NIOSH, 2018; OSHA, 2005; McGeer et al., 2004; U.S. EPA, 2007; U.S. EPA, 2002a; ATSDR, 2007; IARC, 2004a; OEHHA, 2014).

The major challenge in using MOA analyses to reach conclusions about the shape of the dose-response relationship is that mechanisms of arsenic-associated disease induction are complex, inter-related, differentially applicable to cancer and noncancer outcomes under consideration, and likely interoperable in different ways across the concentration ranges tested. There is little evidence that directly addresses this complexity in the low-dose region. Moreover, much of the primary evidence is based on in vitro studies conducted at high concentrations (see Appendix A), raising concerns about applicability to low-dose effects. In other cases, mechanistic evidence comes from rodent studies; these animals are generally considered less susceptible to inorganic arsenic than humans. The MOA analysis for bladder cancer supported findings from epidemiological studies on risk modifiers (i.e., smoking, genetic polymorphisms, methylation capacity) that may affect arsenic associated bladder cancer risk. However, while the MOA evaluation provided additional support by identifying arsenic-specific mechanisms and risk modifiers likely to increase the risk of human bladder cancer, it is uncertain how this information might be used to inform the quantitative dose-response analysis. Conducting a similar analysis for other prioritized outcomes is hindered by the lack of a complete MOA for any health outcome and the likelihood that most, if not all, health outcomes associated with arsenic exposure involve multiple interactive MOAs. These challenges have been long recognized, and the NRC acknowledged uncertainty about whether such analyses would be feasible without further research (NRC, 2013).

The determination to not use animal-based MOA analyses in the dose-response analysis is further supported by both the abundance of epidemiological studies of low-level exposures to arsenic and the increased power and confidence in low-dose extrapolations afforded by new developments in Bayesian meta-regression methods that combine data from multiple studies into a single analysis. The hierarchical Bayesian method allows for the analysis of case-control and cohort studies, as well as low- and high-dose studies, simultaneously. In addition, this approach makes no assumption on the shape of the dose-response curve (i.e., linear vs. nonlinear) or whether a threshold exists, except that it does not allow for a change in the dose-response direction (e.g., a “J” -shaped dose-response curve). In selecting studies for inclusion in these meta-analyses, priority will be given to studies with well-characterized exposures during all life stages, including early life (e.g., pregnancy). Finally, Bayesian meta-regression methods are in line with the 2005 EPA Cancer Guidelines, which recommends that “when several studies are available for dose-response analysis, meta-analysis can provide a systematic approach to weighing positive studies and those studies that do not show positive results and calculating an overall risk estimate with greater precision.” Additional details on the Bayesian meta-regression analysis are summarized below in Section 5.

The approach for dose-response analysis in the iAs assessment is consistent with the 2005 EPA Cancer Guidelines two-step approach to distinguish the dose-response data from inferences made about lower doses: the first step involves analyses in the range of observations made in the experimental and epidemiological studies and the second step involves extrapolation into the lower dose range, taking into consideration what is known about the agents’ MOA (U.S. EPA, 2005a). However, for iAs, the second extrapolation step is not needed because EPA is modeling human data, and the lower range of exposures reported in the epidemiological studies are very near U.S. background exposure levels.

We also note that in 2023, EPA’s Cancer Assessment Review Committee (CARC) of the Office of Pesticides Programs Health Effects Division evaluated a proposed carcinogenic mode of action for inorganic arsenic in accordance with EPA’s Guidelines for Carcinogen Risk Assessment [(EPA Docket EPA-HQ-OPP-2013-0107), https://downloads.regulations.gov/EPA-HQ-OPP-2013-0107-0064/content.pdf]. The purpose of this CARC review was to evaluate the non-genotoxic MOA for iAs-induced tumors of the skin, lung and urothelium proposed by the Organic Arsenicals Product Task Force (OAPTF). The OAPTF proposed MOA for iAs-induced carcinogenesis in skin, lung, and urothelial tissues is cytotoxicity and regenerative proliferation. The OAPTF proposed MOA was described as a threshold process, with a minimum amount of iAs necessary to cause cytotoxicity and the subsequent key events. To evaluate the OAPTF proposed MOA, CARC also reviewed animal cancer bioassay data from the open literature with the goal of identifying tumorigenic doses that could be compared against the experimental data for the preceding key events of the proposed MOA. CARC considered the available data to not adequately support the proposed MOA of cytotoxicity and regenerative proliferation for iAs-induced skin, lung, or urothelial tumors. As a non-genotoxic MOA could not be established, the discussion of a threshold dose was not considered relevant at this time.

The statement that there are no epidemiological data for responses at the low exposure level is inaccurate. Further, as noted earlier in this appendix, the logistic model that was used in the external peer review draft of the iAs is a member of a family of models known as tolerance distribution models. These models assume that each individual has a latent tolerance to a chemical and that adverse effects cannot occur until this threshold is met. The distribution of these individual tolerances is assumed to be logistic with the logistic model. A population threshold defined by studies in animal models or cell lines do not preclude the existence of lower threshold in individuals. To address the comments that the logistic model is not flexible enough to adequately characterize dose-response curves consistent with threshold hold behavior, EPA has applied an extension of the logistic model (i.e., the “logistic-power”) in the main dose-response analysis in the revised assessment.

[underlined: Public Comment:] One commenter (Dr. Samuel M. Cohen) criticized alternative modes of action proposed by EPA as being too reliant on misleading in vitro data. They claim that indirect genotoxicity has been demonstrated only at cytotoxic concentrations, which kill the cells and lead to DNA damage as well as oxidative stress (Cohen et al., 2013; Tsuji et al., 2019) and that these effects do not occur in vivo at the levels to which humans are exposed. They point to the use of in vitro studies of cell lines that are malignant or immortalized, non-transformed as a major problem. The state that “even in cell lines that are non-transformed there are marked abnormalities in several critical genes, such as p53” and that “these genes are involved with cellular processes related to DNA repair, control of oxidative stress and other important cell functions ultimately controlling adverse reactions.”

[underlined: EPA Response:] As discussed in Appendix A of the Systematic Review Protocol (NASEM, 2019) EPA Cancer Guidelines document provides guidelines for developing MOA analyses. The guidelines state that “mode of action conclusions should be [are] used to address the question of human relevance of animal tumor responses, to address differences in anticipated response among humans, such as between children and adults or men and women; and as the basis of decisions about the anticipated shape of the dose-response relationship” [see Sections 2.4.2.2 and 2.4.3.4 of (U.S. EPA, 2005a)]. The IRIS Program routinely conducts MOA analyses to inform hazard identification and dose-response analysis, but a complete understanding of MOA is not required to develop hazard conclusions or toxicity values. In the case of arsenic, the National Research Council (NRC) recommended EPA conduct MOA analyses to facilitate understanding of exposure-response relationships and interindividual variabilities for health outcomes where extrapolation to below the observed range may be necessary. However, the NRC also recognized that it was not clear whether such an analysis would be feasible. Appendix A of the Systematic Review Protocol for the Inorganic Arsenic assessment describes the analyses conducted by EPA to characterize MOAs associated with arsenic exposure, focusing on seven MOAs common to multiple adverse health effects versus tissue-specific descriptions. The various MOAs appear interrelated and are likely to be involved in both cancer and noncancer outcomes. Interrelated MOAs discussed in the appendix included: 1) Reactive oxygen species (ROS) generation and oxidative stress responses; 2) As(III) binding to thiol groups and inhibition of key enzymes; 3) As(V) inhibition of oxidative phosphorylation (As[V] structural analog of phosphate); 4) Cell cycling and damage repair impairment; 5) Epigenetics; 6) Endocrine disruption; 7) Cytotoxicity and regenerative proliferation. Appendix A discusses multiple in vitro cell models that have been characterized to inform inorganic arsenic toxicity, including malignant (e.g., oncogenic cell lines such as HepG2), immortalized (e.g., transformed cell line of non-tumorigenic origin, such as Urotsa), and primary cells lines of mammalian and human origin. Characterization of these various cell lines included evaluations of cytotoxicity. As discussed in various sections and illustrated in Tables A1–A4 of Protocol Appendix A there are many factors that may affect cellular responses to inorganic arsenic including cell type, culture conditions, dose of inorganic arsenic, and duration of exposure. The conclusion of the analyses was that the recognized MOAs for any of the hypothesized bases for inorganic arsenic (iAs)-induced disease are incomplete, poorly populated with key events, and/or nonspecific. This prevents a critical evaluation of dose-response relationships, particularly in the low-dose region.

[underlined: Public Comment:] One commenter (Dr. Samuel Cohen) noted that it has been well documented in the literature that arsenicals do not react with DNA, further claiming this would be the only mode of action that could result in a potential linear, non-threshold dose-response. This commenter then stated that since a linear mode of action is excluded, the dose-response for arsenicals must include a threshold.

[underlined: EPA Response:] EPA is not asserting a genotoxic mode of action for inorganic arsenic and is not using genotoxicity to support a linear dose-response. Because epidemiological studies are available for general populations, EPA did not need to extrapolate far beyond the observed data (i.e., dose-response data were available in the low-dose region down to the estimate background exposure level). This there was no need to develop MOA linear/threshold assumptions for dose extrapolation. The logistic model applied in the external peer review draft of the assessment is a non-linear model that can fit a variety of dose-response shapes, including sigmoidal dose-response curves that are consistent with threshold behavior. Further, the logistic-power model used in the main dose-response analysis in the revised assessment is even more flexible than the logistic model and can fit dose-response data with stronger, sigmoidal shapes.

Regardless, even if a linear mode of action is precluded given mode-of-action data, the IRIS program then does not automatically fit dose-response models that explicitly include a threshold (nor is such a model included in the standard suite of models the IRIS program conducts dose-response analyses with). Rather, established dose-response methodology is to fit flexible models to the data that can describe threshold-like behavior if it is evident in the data being modeled.

## F.4 CHARGE QUESTION 5–LIFETABLE ANALYSES

5) EPA applied lifetable analyses to extrapolate estimates of MR pooled slopes to the desired target population (i.e., general United State population). EPA provides the results of the lifetable analysis as extra risk values calculated for a set of discrete iAs intake values, as well as polynomial trend lines with equations for the extra risk curves so that users can calculate extra risk values for each outcome at any dose they require. For each outcome below, please comment on whether the lifetable methods have been scientifically justified and clearly described.
  a) The Toxicological Review estimates extra risks at various iAs doses for multiple DCS endpoints: cardiovascular disease (CVD) incidence, fatal CVD, ischemic heart disease (IHD) incidence, and fatal IHD. Age stratified mortality values were available for fatal CVD and fatal IHD and were used in the lifetable analysis. Age-stratified DCS morbidity values were not available, and a single lifetime background risk value was used in the analyses for CVD and IHD incidence. At 0.13 μg/kg-day, a lifetime extra risk for CVD incidence of 2.1 × 10−2 was estimated.
  b) The Toxicological Review estimates extra risks at various iAs doses for type II diabetes mellitus. Age-stratified diabetes mortality and morbidity values were not available, and a single lifetime background risk value was used in the analysis. At 0.13 μg/kg-day, a lifetime extra risk for diabetes of 1.8 × 10−2 was estimated.
  c) The Toxicological Review estimates extra risks at various iAs doses for developing bladder cancer. Age stratified mortality and morbidity values were available for bladder cancer and were used in the lifetable analysis. At 0.13 μg/kg-day, a lifetime extra risk for bladder cancer of 7.9 × 10−4 was estimated.
  d) The Toxicological Review estimates extra risks at various iAs doses for developing lung cancer. Age stratified mortality and morbidity values were available for lung cancer and were used in the lifetable analysis. At 0.13 μg/kg-day, a lifetime extra risk for lung cancer 2.4 × 10−3 was estimated.

### F.4.1 SAB Peer Reviewer Comments on Lifetable Analysis (Charge Question 5)

The SAB report states “The general approach for life table estimation is scientifically justified because it follows the standard approach (Crump and Allen, 2011) used in other risk assessments, such as the IRIS Toxicological Review of Libby Amphibole Asbestos. However, in the draft document it was unclear how the general methodology was applied in this assessment including how the meta-regression slopes were incorporated into the life tables. During the in-person public meeting, the EPA provided a more detailed explanation on how the calculations were performed including screenshots of the Excel spreadsheets used in the calculations. It was then understood that the following methodology was used:

i. Population data were used to obtain age-specific incidence rates at an assumed background dose. The U.S. median background dose of iAs was assumed to be 0.0365 µg/kg-day.
ii. Slope estimates from the Bayesian meta-regression were used to convert the incidence rate at background to incident rate at zero dose, which provides an intercept for a logistic regression model for age-specific incidence.
iii. The corrected intercept and slope were then used to calculate age-specific incidence and age-specific probability of disease at a given dose. This calculation assumed a constant exposure to iAs over a lifetime, which is a reasonable simplifying assumption since drinking water iAs often has more geographical variability than temporal variability.
iv. The age-specific probabilities were then summed to obtain the lifetime risk of disease.

The EPA needs to provide this level of transparency in the description of the Lifetable Analysis method to estimate lifetime extra risk for the target population in the supplementary materials for the iAs assessment. It is recommended that the EPA provide a worked example in the supplementary materials which translates the general equations (in page C-27 and C-28, Appendix C of the Supplemental Materials document) to quantities from the meta-regression and includes a table which clearly shows the steps of the calculation. For cases where the calculations are considerably different (e.g., when only lifetime risk is available), clear explanation should be provided on how the calculations differ from the worked example provided earlier.” The panel included as tiered comments several recommendations for EPA to more clearly and transparently describe the lifetable methodology applied in the assessment.

The SAB panel’s tiered comments on Charge Question 5 were:

- 0 Tier 1 Recommended Revision
- 5 Tier 2 Suggested Revisions
- 2 Tier 3 Future Considerations

#### Tier 1 Recommendations for Charge 5

The reviewers had no Tier 1 recommendations.

#### Tier 2 Suggestions for Charge 5

[underlined: SAB Suggestion (1 of 5 Tier 2 for Charge 5):] Provide more detail in the supplementary materials on how the lifetable calculations were performed, including a worked example and an explanation of required modifications when age-specific incidence rates are not available. The explanation should be comprehensible to a diverse scientific audience.

[underlined: EPA Response:] The way EPA applied the lifetable analysis has been extensively re-worked in the revised assessment. Namely, all the lifetable calculations are now conducted in R and extensive documentation is provided in-line in the lifetable code along with a stand-alone data dictionary explaining all variables and a worked example. For outcomes where age-specific incidence rates are not available, modified R code is used for lifetable calculations and explanations of the modifications are again provided in the code and in the text of the assessment. A worked example using bladder cancer has been included in Section C.1.1: Estimation of Lifetime Extra Risk in the U.S. (Lifetime Analysis Methods): Example Application of Lifetable Methodology.

[underlined: SAB Suggestion (2 of 5 Tier 2 for Charge 5):] Provide clearer citations for the population risk values used in the lifetable calculations.

[underlined: EPA Response:] Citations for the data sources that are used to define population lifetime probabilities of disease used in lifetable calculations have been moved from the end of the outcome-specific appendix sub-sections to the beginning section. Additionally, for outcomes where no age-stratified mortality or morbidity data exist to generate lifetime probabilities from birth, summary statistics for lifetime probability are used and the specific starting age for that lifetime probability are clearly reported in the revised assessment (see Sections 4.3.4, 4.3.7, and 4.3.8).

[underlined: SAB Suggestion (3 of 5 Tier 2 for Charge 5):] Discuss or, if possible, examine the impact of using different starting ages and stratification by race/ethnicity and sex in the lifetable calculations for CVD incidence and diabetes.

[underlined: EPA Response:] Using different starting ages in the lifetable analysis is of limited value as EPA CSF and RfD derivations are for lifetime exposures. The lack of age-specific lifetime risk data that is stratified by race/ethnicity or sex precludes the development of separate lifetable analyses by these factors. EPA does, however, discuss the impact of these factors as “Risk Modifiers” in the “Evidence Synthesis” section of the assessment, Section 3.2.

[underlined: SAB Suggestion (4 of 5 Tier 2 for Charge 5):] Remark on the possible differences by country if a relevant U.S. reference for lifetime risk cannot be identified.

[underlined: EPA Response:] Given that ischemic heart disease (IHD) incidence has now replaced cardiovascular disease (CVD) incidence in the assessment, all mortality, morbidity, or lifetime probability of disease data used in the revised assessment come from U.S. reference populations and are identified as such in the revised assessment.

[underlined: SAB Suggestion (5 of 5 Tier 2 for Charge 5):] Explain the purpose of the extra risk curves and include a table containing the equations for the fitted curves.

[underlined: EPA Response:] The discussion on purpose of the extra risk curves has been expanded in the revised assessment. Equations for the linear and polynomial trend lines for the extra risk curves are more clearly reported (in both tabular form and in the text of the assessment). In the revised assessment, cancer slope factors were calculated as the linear slope from 0.2 µg/kg-day to zero dose. The daily intake value of 0.2 µg/kg-day was selected as the upper limit for the estimation of the cancer slope factor given that Mendez et al. (2017) reports that the 95th percent upper bound on drinking water concentrations in the United States is 15.4 µg/L. This drinking water concentration translates to daily intake value of 0.19 µg/kg-day iAs using a 0.011 L/kg-day water consumption rate and accounting for 0.02 µg/kg-day daily iAs exposure via the diet. Therefore, the providing a linear CSF below this daily dose covers the majority of drinking water exposure scenarios in the United States.

#### Tier 3 Future Consideration Charge 5

[underlined: SAB Future Consideration (1 of 2 Tier 3 for Charge 5):] If data are available, perform sensitivity analyses to account for proportions of study populations that are not exposed to a constant level of iAs over their lifetime.

[underlined: EPA Response:] IRIS assessments typically assume a constant lifetime exposure to a chemical when calculating reference values and cancer unit risk or slope factor estimates. This was the approach used in the iAs assessment to be consist with IRIS methodologies, but also to simplify lifetable calculations. Sourcing age-stratified inorganic arsenic drinking water and dietary exposures would not be straightforward but could be considered for future arsenic assessments. Other assessments were age-stratified exposure information is readily available could use a modified lifetable approach to account for differences in background exposure throughout a lifetime.

[underlined: SAB Future Consideration (2 of 2 Tier 3 for Charge 5):] In future assessments, the EPA should use the results from the Bayesian meta-regression to generate a posterior distribution for extra risk at selected dose values.

[underlined: EPA Response:] The assessment has been revised so that lifetable calculations in R now use the full set of MCMC iteration-specific inputs from the dose-response modeling rather than just the summary statistics (i.e., 5th percent lower bound, mean, and 95th percent upper bound). Therefore, the lifetime extra risks that are now reported in the assessment represent the summary statistics of the full posterior distribution of lifetime extra risks and the full posterior distribution is provided in the modeling files. Additionally, a fuller set of doses (i.e., more doses) are used in the lifetime extra risk calculations to better characterize how lifetime extra risks differ across the dose-range.

### F.4.2 Public Comments on Lifetable Analyses (Charge Question 5)

[underlined: Public Comment:] Two commenters (Dr. Kan Shao; Electric Power Research Institute) noted that it was unclear how risk at zero inorganic As dose was calculated in a US population, with one of the commenters (Electric Power Research Institute) asking whether it was derived by extrapolation of logistic slope estimates. One of these commenters suggested the assessment should briefly describe how the estimated risk at zero dose was used.

[underlined: EPA Response:] The commenter is correct that risk in a hypothetical US population at zero iAs exposure was estimated in the external peer review draft by using the estimated logistic model slope (and logistic model equation) to back-calculate the risk assuming baseline risks (i.e., risks calculated from the mortality and morbidity data) were associated with the assumed background exposure level of 0.0365 µg/kg-day. In the revised assessment, the logistic-power model is now used in the dose-response analyses in the main assessment and thus, risk at zero iAs exposure is now estimated using both the logistic slope and the power parameter value. The assessment has been revised to make this point, and other aspects of the modeling, clearer (see Section C.1.1: Bayesian Dose-Response Meta-Analysis Methods and C.1.1: Estimation of Lifetime Extra Risk in the U.S. [Lifetable Analysis Methods]). This includes explicitly stating how this risk at zero inorganic As exposure was used in subsequent calculations.

[underlined: Public Comment:] One commenter (Environmental Integrity Project and Earthjustice) requested that EPA present lifetime extra cancer risks at the 95% upper bound to better align with the proposed cancer slope factors.

[underlined: EPA Response:] The document presents both the central estimate of lifetime extra risks and the 5% lower and 95% upper bounds of that risk in the tabular presentation of results (see Sections 4.3.5, 4.3.6, 4.3.7, and 4.3.8 and Tables 4-3, 4-5, 4-7, and 4-9). The assessment has been revised to make this clearer.

## F.5 CHARGE QUESTION 6–CANCER SLOPE FACTORS

6) Based on the lifetable analyses for lung cancer and bladder cancer, linear trend lines were used to estimate a cancer slope factor (CSF). These CSFs were estimated using only risks derived in the low-dose region given non-linearity at higher doses. Please comment on whether the selected CSF values are scientifically justified and clearly described.

### F.5.1 SAB Peer Reviewer Comments on Cancer Slope Factors (Charge Question 6)

The SAB panel report states “The CSFs for lung cancer, bladder cancer, and combined cancer risk are based on data indicating a linear dose-response relationship in the low-dose region. The 95% upper bound extra risk estimates were used to calculate the linear slopes, which are analogous to EPA CSFs. These CSFs appear to be scientifically justified for estimation of risks in the low-dose range (<0.22 µg/kg-day). However, the draft document states (see Tables ES-1; Figures 4-7 and 4-9; p. 4-67, lines 12–15) that the dose-response is non-linear at doses above 0.22 µg/kg-day and that the “risk estimates should not be obtained using the CSF” above that dose (p. ES-3, lines 5–7).

The CSFs appear to be scientifically justified. However, several aspects of the explanations of the cancer risk estimates need to be revised to ensure that the information is clear to the reader.” The panel then provided multiple bulleted recommendations regarding the presentation of cancer slope factors in the assessment (see report for full details).

The SAB panel report additionally states “The protocol for the draft IRIS assessment, which was reviewed and approved by NASEM (2019), includes analyses of the uncertainties associated with several parameters used in CSF development. These analyses include inferred probability distributions for each conversion factor used in the estimation of iAs intake, Monte Carlo analysis to obtain the MLE, low-end, and high-end values for iAs intake, use of the effective count approach for odds ratio or relative risk to account for confounding bias in the studies included in the meta-regression analysis, and Bayesian meta-regression analysis in the dose-response analysis. However, the draft IRIS document does not appear to include a section that describes uncertainty characterization as it is discussed in the IRIS Handbook (USEPA, 2022). Section 8.4 of the IRIS Handbook, “Characterizing uncertainty and confidence in toxicity values,” recommends that an assessment should–at least qualitatively–address principal sources of uncertainty (USEPA, 2022). The Handbook describes several factors that commonly affect the level of uncertainty, including consistency in the overall database (specifically noting that the variability among candidate values for the same outcome be evaluated, taking into account explanations for differences), dose metrics used for dose-response modeling, model uncertainty, and statistical uncertainty. In addition to the characterizations of uncertainty already included in the draft document, it is recommended that a stand-alone discussion of the qualitative and quantitative uncertainties associated with the CSF in the context of the recommendations in the IRIS Handbook (USEPA, 2022) be added.”

The SAB panel’s tiered comments on Charge Question 6 were:

- 3 Tier 1 Recommended Revisions
- 3 Tier 2 Suggested Revisions
- 1 Tier 3 Future Considerations

#### Tier 1 Recommendations for Charge 6

[underlined: SAB Recommendation (1 of 3 Tier 1 for Charge 6):] When cancer risk values are discussed, it should be made clear whether they represent the mean or the 95% upper bound estimate.

[underlined: EPA Response:] The assessment has been revised and QA checked to ensure that when lifetime risks are presented, the text, tables, or figures are clear whether the central estimate or 95% upper bound estimate is being reported. Typically, in the text the lifetime extra risks are central estimates with the 5th–95th percentile confidence interval reported. When cancer slope factors are discussed (or approximation equations provided), the 95th percentile upper bound is being used and/or reported.

[underlined: SAB Recommendation (2 of 3 Tier 1 for Charge 6):] The explanation of cancer risk that is associated with 1 µg/kg-day dose (p. ES-2, line 33–p. ES-3, line 1; p. 4-67, lines 15–17 [EPA: note these are page and line numbers in the External Peer Review draft of the iAs assessment]) be rephrased to say that the CSFs, in units of (µg/kg-day)-1, are the slopes of the relationship between risk (unitless) and dose (µg/kg-day), and that they only apply to doses up to 0.22 µg/kg-day.

[underlined: EPA Response:] The description of the cancer slope factors and approximating equations have been revised in the assessment (see Sections ES.2 and 4.7).

[underlined: SAB Recommendation (3 of 3 Tier 1 for Charge 6):] Consistent with IRIS Handbook, an uncertainty section should be added to the document summarizing uncertainties in the cancer assessment and resulting slope factor.

[underlined: EPA Response:] An extensive new section (see Section 4.3.9) has been added to the revised assessment that discusses multiple factors that affect the level of variability and uncertainty in the dose-response assessments. Specifically with regards to the dose-response meta-analysis methods applied in the iAs assessment database consistency, conversion to a common dose metric, derivation of effective counts, the El-Masri-Kenyon PBPK model, dose-response model uncertainty, statistical uncertainty in the POD, and study evaluation are thoroughly discussed.

#### Tier 2 Suggestions for Charge 6

[underlined: SAB Suggestion (1 of 3 Tier 2 for Charge 6):] Cancer risks should be presented in terms of both µg/kg-day and µg/L (assuming standard consumption rate) where both units are relevant.

[underlined: EPA Response:] EPA IRIS assessment express oral doses associated with risk levels in units of µg/kg-day or mg/kg-day. Estimates of corresponding drinking water levels are made outside of the IRIS assessment for either risk management or site-specific mitigation purposes.

[underlined: SAB Suggestion (2 of 3 Tier 2 for Charge 6):] The approach used to account for background exposures in the lifetable analyses should be clearly presented, and the document should discuss that the “estimated background” cancer risks (from dietary exposure, with no additional exposure from drinking water) are much higher than the cancer risk range of 1 in 10,000 to 1 in 1,000,000 usually used by EPA.

[underlined: EPA Response:] A presentation of the risks associated with background exposures (consisting of drinking water and dietary exposures) to inorganic arsenic has been added to the revised assessment in Sections 4.3.5, 4.3.6, 4.3.7, and 4.3.8. Additionally, a new table has been added Section 4.3.10 (Summary of Bayesian Dose-Response Meta-Analysis Results) that collate these same lifetime extra risks, but also reports side-by-side the various linear and polynomial trendlines calculated for bladder cancer, lung cancer, IHD, and diabetes.

[underlined: SAB Suggestion (3 of 3 Tier 2 for Charge 6):] Consider adding discussion of how uncertainties related to systemic bias, residual bias, and uncontrolled confounding were considered for each outcome.

[underlined: EPA Response:] Systematic bias, residual bias, and uncontrolled confounding are considerations in the study evaluation process that all studies in the assessment underwent prior to inclusion in the dose-response analysis. Additional details on the study evaluation process as well as examples of key confounders considered for each health outcome are described in Section 1.6.2. Studies that advanced from hazard identification to dose-response were considered to be at low risk for systematic bias, residual bias, and uncontrolled confounding, (in the assessment, all such studies are medium or high confidence). Additional details for each specific study can be found in HAWC. Section 4.3.9 (Variability and Uncertainty in Bayesian Dose-Response Meta-Analyses) has also been added to the revised assessment, wherein these topics are additionally discussed.

#### Tier 3 Future Consideration Charge 6

[underlined: SAB Future Consideration (1 of 1 Tier 3 for Charge 6):] Estimation of risks in the lifetable analysis using the individual iterates of the Bayesian analysis should be considered.

[underlined: EPA Response:] The assessment has been revised so that lifetable calculations in R now use the full set of MCMC iteration-specific inputs from the dose-response modeling rather than just the summary statistics (i.e., 5th percent lower bound, mean, and 95th percent upper bound). Therefore, the lifetime extra risks that are now reported in the assessment represent the summary statistics of the full posterior distribution of lifetime extra risks.

### F.5.2 Public Comments on Cancer Slope Factors (Charge Question 6)

[underlined: Public Comment:] One commenter (Dr. Kan Shao) suggested that the model parameters (i.e., “slope”) used to calculate lifetime extra risk were not consistent when using a lifetable. Consequently, the results (between the logistic, FP, and DH models) are not comparable.

[underlined: EPA Response:] This commenter highlights use of the word “slope” in the description of how the lifetable method uses the parameter values from the logistic, FP, or DH model when calculating lifetime extra risk. However, it is the lifetime extra risks that are being compared to one another, not the model parameter values. Different model parameters can have different interpretations and the lifetable approach uses those parameter values appropriately in their respective model equations to calculate lifetime extra risks. Suggesting that these risks are not comparable given the different parameters and model forms is an inappropriate conclusion. Such a conclusion would be tantamount to claiming that responses estimated by ‘normal’ benchmark dose models (e.g., logistic, probit, Gamma) are not comparable because parameters between those models are different. A description of how EPA applied the lifetable method to calculate lifetime extra risks has been revised for clarity in Section C.1.1: Estimation of Lifetime Extra Risks in the U.S. (Lifetable Analysis Methods): Example of Application of Lifetable Methodology. Ultimately, the SAB panel concluded that EPA’s application of the lifetable methodology was “… scientifically justified because it follows the standard approach … used in other risk assessments, such as the IRIS Toxicological Review of Libby Amphibole Asbestos.” More details on how the lifetable method was applied in the iAs Toxicological Review, including how the slope parameters were used to estimate lifetime extra risk, has been added to the assessment (see EPA response to SAB Suggestion (1 of 5 Tier 2 for Charge 5) above).

[underlined: Public Comment:] Multiple commenters (Dr. Kan Shao, Superfund Settlement Project and RCRA Corrective Action Project; Electric Power Research Institute) provided comments on the derivation of the cancer slope factors. One commenter (Dr. Kan Shao) expressed concern over the linear dose-response relationship assumed below 0.22 µg/kg-day and stated that it was not well justified and questioned why the two-step dose-response assessment process (i.e., POD derivation and low dose extrapolation) was used given the fact that some of the epidemiological studies used for dose-response analysis were already in the low dose range. Another commenter (Superfund Settlement Project and RCRA Corrective Action Project) asked for clarification on whether any other method besides visual inspection was used to determine if lifetime extra risks were linear below 0.2 µg/kg-day. They also commented that the lifetime extra risk plots do not identify the source of the data points. Additionally, this commenter (Superfund Settlement Project and RCRA Corrective Action Project) stated that the model predictions should be overlaid with actual data to provide visual evidence of the appropriateness of model assumptions. One commenter (Electric Power Research Institute) stated the justification for the cut-off value of 0.22 µg/kg-day was not clear.

One commenter (Dr. Kan Shao) objected to the “high uncertainty” of using linear or polynomial trendlines to approximate the exact lifetime extra risks calculated from the lifetable analysis. This commenter further states that there is no data in the low dose range and that EPA should use traditional low dose extrapolation methods to calculate slope factors or reference doses. This commenter noted that the combined cancer slope factor was calculated based purely on a mathematical basis without biological or toxicological justification, and that the assumption of normality for the individual slope factors is not sufficiently justified.

[underlined: EPA Response:] To avoid confusion on the lifetime extra risk plots, EPA has revised the description of the linear CSF and polynomial trendlines. In the revised assessment, the linear trendline for the 95th percent upper bound on lifetime risks estimated below 0.2 µg/kg-day is presented as the cancer slope factor. The value of 0.2 µg/kg-day was chosen as the upper dose value with which to estimate the trendline because this value covers the majority of exposure scenarios in the United States. Briefly, Mendez et al. (2017) reports that the 95th percent upper bound on drinking water concentrations in the United States is 15.4 µg/L. This drinking water concentration translates to daily intake value of 0.19 µg/kg-day iAs using a 0.011 L/kg-day water consumption rate and accounting for 0.02 µg/kg-day daily iAs exposure via the diet. Therefore, the providing a linear CSF below this daily dose covers the majority of drinking water exposure scenarios in the United States. The revised assessment still provides the polynomial fit to the lifetime extra risks in addition to the linear CSF (see Sections 4.3.5, 4.3.6, 4.3.7, and 4.3.8). Figure captions have been revised to make clear where the lifetime risk values come from.

Regarding the request for model fit graphs, the external peer review draft of the iAs assessment contained an extensive modeling appendix (see Section C.1.2) that presented tabular and graphical outputs for all dose-response meta-analysis; this appendix is retained in the final assessment.

It should be emphasized that the lifetime extra risk graphs were not used to derive a point of departure for low-dose extrapolation. No low-dose extrapolation was done in the presentation of lifetime extra risks because the data the dose-response modeling was based on already contained low-dose data, i.e., exposure levels in some studies were in the low-dose region and even approached background levels.

The lifetime extra risk graphs represent a fitting of a trendline to the lifetime extra risks (explicitly calculated using the lifetables) such that an approximate lifetime extra risk can be calculated at any iAs exposure level. EPA provides the dose-response materials (i.e., lifetable code) so that risk managers can calculate explicit lifetime risks. In the endpoint-specific modeling sections, EPA reports transparently how much the approximate lifetime extra risks estimated from the trendlines deviate from the exact lifetime extra risks calculated from the lifetable. EPA has also conducted a sensitivity analysis comparing the trendlines estimated from varying numbers of lifetime extra risks given different numbers of doses. The results of this sensitivity analysis show that varying the number of lifetime extra risks has almost no impact of the estimation of the trendlines.

It is inaccurate to state that there is no dose response data in the low dose region, as evident in the input data tables in Section C.1.2 of the appendix. With respect to cancer modeling, a cancer slope factor (CSF) is a value that expresses the incremental increased risk of cancer incidence from exposure to a substance per unit dose; in practice it is calculated as C S F = (B M R)/(B M D L) , where the BMR is the benchmark response and the BMDL is the 95% lower limit on the benchmark dose. In the arsenic assessment, the availability of low dose data obviates the need of low dose extrapolation. Thus, EPA has chosen instead to estimate the slope of the cancer risks calculated via the lifetable methodology across the entire range of doses. Thus, the equation of the trendline for the explicitly calculated lifetime extra risks gives users an approximate method to calculate lifetime extra risks. To ensure that the approximated lifetime risks provide answers very close to those that would be obtained if users instead ran the lifetable approach themselves, again, EPA reports the magnitude to which approximate lifetime extra risks obtained from the linear and polynomial trendlines deviate from lifetime extra risks obtained directly from the lifetable.

The assessment retains the estimation of a combined cancer slope factor. In brief, both EPA’s Cancer Guidelines (U.S. EPA, 2005a) and the NRC Science and Judgement report (NRC, 1994) support estimation of aggregate cancer potency when data exists that multiple tumors are caused by exposure to the chemical of interest.

Ultimately, the SAB panel concluded that EPA’s approach to estimating the cancer slope factor was scientifically justified, stating “The CSFs for lung cancer, bladder cancer, and combined cancer risk are based on data indicating a linear dose-response relationship in the low-dose region. The 95% upper bound extra risk estimates were used to calculate the linear slopes, which are analogous to EPA CSFs. These CSFs appear to be scientifically justified for estimation of risks in the low-dose range (<0.22 µg/kg-day).”

[underlined: Public Comment:] One commenter (Dr, Kan Shao) disputed EPA’s characterization that it took a “more consistent, unified approach for cancer and non-cancer endpoints” to be aligned with NRC’s recommendations. This commenter interprets the NRC’s (2009) recommendations for a more unified approach for cancer and non-cancer outcomes as focusing mostly on low-dose extrapolation and commented that the iAs IRIS assessment still uses different low-dose extrapolation methods (i.e., linear vs. non-linear) and that the IRIS assessment didn’t take an essential step towards a unified approach for cancer and non-cancer outcomes. Another commenter (Exponent) commended EPA for planning a far more comprehensive assessment that applies an approach for integrating cancer and noncancer effects and broadens the dose-response assessment to include multiple studies, but expressed concern that EPA appears to be setting aside the mechanistic and animal data as less useful or not needed because the human data can be modeled.

[underlined: EPA Response:] The iAs assessment applies the same Bayesian dose-response meta-analysis and lifetable framework to both cancer and non-cancer outcomes to be able to calculate lifetime extra risks for those outcomes. Typically, in IRIS assessments, lifetime extra risks are not calculated for non-cancer outcomes and only calculated for cancer outcomes as slope factors. In this context, the iAs IRIS assessment represents a step towards a unified approach for cancer and non-cancer outcomes where lifetime extra risks are calculated for all outcomes. The SAB panel supported this unified approach, stating “[t]hese analyses harmonize the approaches used for cancer and noncancer effects, in accordance with previous recommendations to EPA from several advisory groups. Consistent evaluation of the several noncancer and cancer endpoints occurring with iAs exposure is scientifically appropriate based up the results of the dose-response analysis.”

The assessment provides lifetime extra risks for both non-cancer and cancer endpoints, polynomial equations to approximate lifetime extra risks for cancer outcomes and organ-specific candidate values and an overall RfD for non-cancer outcomes to meet the diverse needs of the risk managers utilizing this assessment. The presentation of probabilistic lifetime extra risks and deterministic candidate values (and overall RfD) for non-cancer endpoints is unique in IRIS assessments.

In the 2019 NASEM review of the iAs Protocol (NASEM, 2019), the majority of the review committee concluded that “[b]ecause EPA will rely on epidemiological data and will be performing dose-response analyses within the range of observation … MOA data were unnecessary for determining the shape of the dose-response curve unless EPA finds it necessary to extrapolate to lower levels.” Given the modeling in the iAs Toxicological Review included data approaching background exposure levels, low dose extrapolation was unnecessary and the decision to not use MOA data to inform the shape of the dose-response curve is consistent with NASEM’s conclusions.

[underlined: Public Comment:] One commenter (Dr. Kan Shao) objected to the assessment’s characterization that “EPA’s modeling approach in this assessment does not assume linearity.” This commenter claimed this description was not accurate given that two-levels of dose-response analysis were used in the assessment that explicitly assumed or employed linearity, including using only the slope parameter of the logistic model (or FP and DH models) to calculate lifetime extra risks (i.e., the non-linear dose-response relationship of these models was not directly used) and the fitting of a linear trend line to the lifetime extra risks in the low-dose region of the exposure range.

[underlined: EPA Response:] It is not accurate that EPA only used the logistic slope parameter to calculate lifetime extra risks in the lifetable analysis. The non-linear dose-response model equation (i.e., logistic-power model) is used to estimate both the lifetime risk at zero exposure (i.e., the response at no exposure) and the lifetime risk at various iAs exposure levels using both the estimated logistic slope and power parameter values. Thus, the non-linear nature of the model was used in the calculation of the lifetime extra risks. Regarding the trendlines fit to the lifetime extra risks, EPA has revised the description of the linear CSF and polynomial trendlines. In the revised assessment, the linear trendline for the 95th percent upper bound on lifetime risks estimated below 0.2 µg/kg-day is presented as the cancer slope factor. The value of 0.2 µg/kg-day was chosen as the upper dose value with which to estimate the trendline because this value covers the majority of exposure scenarios in the United States. Briefly, Mendez et al. (2017) reports that the 95th percent upper bound on drinking water concentrations in the United States is 15.4 µg/L. This drinking water concentration translates to daily intake value of 0.19 µg/kg-day iAs using a 0.011 L/kg-day water consumption rate and accounting for 0.02 µg/kg-day daily iAs exposure via the diet. Therefore, the providing a linear CSF below this daily dose covers the majority of drinking water exposure scenarios in the United States. The revised assessment still provides the polynomial fit to the lifetime extra risks in addition to the linear CSF derived for doses below 0.2 µg/kg-day (see Sections 4.3.5, 4.3.6, 4.3.7, and 4.3.8).

[underlined: Public Comment:] One commenter (Electric Power Research Institute) stated that, while analyses were conducted to determine the effect on the beta mean, it was not clear if any analyses were conducted to ensure that a single study was not causing a significant effect on the CSF.

[underlined: EPA Response:] In the revised assessment, a leave-one-out sensitivity analysis was conducted to determine whether any single studies were highly influential in the estimation of the beta mean. These sensitivity analyses are documented in the assessment modeling appendix (see endpoint-specific sensitivity sections in Section C.1.2). In all dose-response meta-analyses, there were studies that did have large impacts on the estimation of the pooled slope parameter. The most influential studies for each endpoint were: the Wu et al. (2013) study for bladder cancer (68% reduction in pooled slope), the Ferreccio et al. (2000) study for lung cancer (65% reduction in pooled slope), the Coronado-González et al. (2007) study for diabetes (50% increase in pooled slope), and the James et al. (2015) study for IHD (61% decrease in pooled slope).

Perpetuating the leave-one-out analysis through the calculation of cancer slope factors was not performed as it logically follows that if a study is highly influential in the estimation of the beta mean (e.g., removing that study results in a sizable change in the beta mean) that that study would also be highly influential in the estimation of the cancer slope factor. For example, in the case of bladder cancer, leaving the Wu et al. (2013) out of the modeled set of studies results in a large reduction (68%) in the value of the beta mean parameter. Lifetime extra risks estimated using this reduced beta mean value would be correspondingly lower and a CSF estimated from those lifetime extra risks would also be correspondingly shallower.

[underlined: Public Comment:] One commenter (Arsenic Science Task Force) recommended that EPA should consider its proposed cancer slope factor in the context of other credible assessments by leading authoritative health agencies.

[underlined: EPA Response:] Appendix G in the iAs assessment includes a table of other health agency’s hazard conclusions and/or toxicity values. Overall, there are some similarities across these assessments. For example, numerous cancer assessments (FDA, 2016; CFSAN, 2023; ATSDR, 2007, 2016) also rely on epidemiological data (versus animal data) to derive cancer toxicity values or exposure limits. It is important to note, however, that EPA performs an independent analysis of the available evidence. This means EPA may arrive at different conclusions than those drawn by others. The discussion and comparison of decisions across different agencies with different decision contexts, mandates, and guidelines is outside the scope of an IRIS assessment.

[underlined: Public Comment:] One commenter (Arsenic Science Task Force) noted that characterizing iAs carcinogenic potential in a dose-response meta-analysis is complicated by significant variations in exposures to background iAs in the diet, heterogeneity between study populations around the world in factors that can influence the toxicity and carcinogenicity of arsenic (e.g., nutritional status and genetics) and differences in the prevalence of important bladder and lung cancer risk factors (e.g., smoking).

[underlined: EPA Response:] With respect to dietary exposures, the specific dietary exposure factor used to convert study-specific exposure metrics to the unified metric of daily intake was selected to represent, as closely as possible, the population the individual studies were conducted in. Dietary exposures reported in the studies were preferred and used if available. If not available, dietary exposures for similar populations and reported in other studies or dietary exposure information for the nationality of the study population were used. This approach considers inter-population differences in dietary exposure to iAs. Also, heterogeneity of study populations was partially accounted for through a variety of sensitivity analyses to investigate how different sets of studies impacted the dose-response analysis; these included leave-one-out analyses, including vs. excluding urinary studies, high vs. low exposure analyses, etc. (see Sections 4.3.5, 4.3.6, 4.3.7, 4.3.8, and C.1.2).

[underlined: Public Comment:] One commenter (Environmental Integrity Project and Earthjustice) stated that presenting cancer slope factors at the 95% upper bound alongside lifetime extra risks at the mean is confusing and the numbers don’t appear to be consistently reported throughout the assessment.

[underlined: EPA Response:] The lifetime extra risks reported in results tables in the assessment include the central estimate of the lifetime extra risks along with 5% lower bound and 95% upper bound estimates. When lifetime extra risks are discussed in the text, these usually refer to the central estimate. To calculate the cancer slope factor, trendlines were fit to the 95% upper bound on lifetime extra risk across a wide range of possible exposures. This method (i.e., using the 95% upper bound on risk) is consistent with EPA guidelines. For example, see Table 4-3: lifetime extra risks for bladder cancer at 0.13 µg/kg-d exposure are reported as 7.87E-4 (8.0E-5–22.4E-3) and the CSF for bladder cancer reported as 1.76E-2 (µg/kg-d-1). The 95% upper bound on lifetime extra risks reported in Table 4-3 can be approximated for this exposure level from the CSF: 1.76 × 10^− 2^ p e r (μ g)/(k g) − d a y × 0.13 (μ g)/(k g) − d a y = 22.8 × 10^− 3^ . Using the linear CSF to approximate lifetime extra risks is valid for exposure levels below 0.2 µg/kg-day. The assessment has been revised to clarify when mean lifetime extra risks are discussed vs. 95% upper bounds.

[underlined: Public Comment:] One commenter (Arsenic Science Task Force) stated that “based on a publication by Xue et al. (2010), the draft IRIS assessment assumes an average daily dietary arsenic intake of 0.02 μg/kg body weight (i.e., a daily intake of 1.6 μg/d for an 80 kg adult)” and that this is lower than other estimates of dietary intake from various foods (Schoof et al., 1999a; Schoof et al., 1999b; EFSA, 2014) and rice (FDA, 2016). They noted that, if the EPA’s proposed CSF were applied to these higher estimates of average dietary arsenic intake the associated risks would be well above the US EPA’s permissible acceptable risk range.

[underlined: EPA Response:] The EPA’s CSF for arsenic represents an upper bound estimate of the increased risk associated with each μg/kg body weight unit increase of drinking water (not dietary) arsenic intake. It is therefore inappropriate to apply it to a dietary intake level. In deriving the background estimate of exposure, EPA used the median dietary estimate from Xue et al. (2010) of 0.02 μg/kg-day in conjunction with median drinking water level estimate obtained from Mendez et al. (2017) of 1.5 μg/kg. The median as an estimate of the central tendency is preferred when data are skewed as it is more resistant to outliers than the mean. Given that the mean estimate of dietary exposure from Xue et al. (2010) is 0.05 μg/kg-day, it clear that the dietary estimates reported in Xue et al. (2010) are right-skewed. Therefore, the use of the median dietary and median drinking water concentrations are retained in the final assessment and the estimated background exposure of 0.0365 μg/kg-day iAs is used in all lifetable and benchmark dose calculations.

[underlined: Public Comment:] One commenter (Exponent) stated that taking data from epidemiologic studies, converting them to a common dose metric, and then modeling the dose-response using a Bayesian meta-regression analysis based on curve fitting that includes the high-dose data will almost certainly produce a linear non-threshold relationship at low doses. Further, this commenter states that various confounding factors and sources of bias in the epidemiological studies, if not considered, will favor linear non-threshold shapes at low doses even for underlying data that are threshold or sublinear in nature.

[underlined: EPA Response:] EPA’s dose-response model of choice, the logistic-power model, is not inherently linear, nor is it being compared to other models, in the sensitivity analyses, that are linear. In particular, the sensitivity analyses investigated models that could in fact be non-monotonic or assume shapes that would closely mimic a threshold behavior. To the extent possible given the nature of published literature and the adjustments incorporated by the original investigators, EPA has applied methods that adjust for confounding factors and sources of bias, including through the use of effective count estimates. EPA considers it inappropriate to systematically ignore “high-dose data,” even if the concept of what constitutes “high-doses” was obvious. In cases where model fit was deemed insufficient given fit criteria described in the assessment, high dose groups were dropped on a study-by-study basis in an attempt to improve overall model fit to the data. This is thoroughly described in the assessment.

## F.6 CHARGE QUESTION 7–NON-CANCER RFD CANDIDATE VALUES

7) EPA calculated a non-cancer RfD based on candidate values for each individual noncancer health outcome considered for dose-response analyses and presents the results of these analyses in Sections 4.6.
  a) EPA determined that data from the (Wasserman, 2014) study on developmental neurocognitive effects were not appropriate for candidate value derivation given the strong nonlinearity observed in the relationship between iAs exposure and IQ scores. Please comment on whether this approach is scientifically justified and clearly described.
  b) To estimate candidate values for DCS and diabetes, the meta-regression pooled slope and upper confidence limit were used to calculate a 5% response level BMD05 and BMDL05, respectively. Please comment on whether this approach and the organ-specific candidate values below are scientifically justified and clearly described.
    i. For DCS, an organ-specific candidate BMDL05 value of 0.094 μg/kg-day was derived based on increased CVD incidence.
    ii. For diabetes, an organ -specific candidate BMDL05 value of 0.13 μg/kg-day was derived.
c) For pregnancy outcomes, decreased birth weight was selected for benchmark dose modeling and the study-reported linear regression slope was used to estimate an organ-specific candidate BMDL05 value of 0.23 μg/kg-day. Please comment on whether this approach is scientifically justified and clearly described.

### F.6.1 SAB Peer Reviewer Comments on Non-Cancer RfD Candidate Values (Charge Question 7)

The panel commented on EPA’s decisions for each noncancer health effect (and associated candidate values), as summarized separately for each effect below.

The panel provided recommendations regarding EPA’s decision in the external review draft to not derive a candidate RfD value for developmental neurocognitive effects based on the associations between iAs exposure and IQ scores observed in the Wasserman et al. (2014) study. The SAB Panel report noted that “EPA concluded that “the currently available evidence indicates that iAs exposure likely causes neurodevelopmental effects in humans given sufficient exposure conditions” and stated that this conclusion was primarily based on human studies showing cognitive effects at drinking water concentrations of <100 µg/L.” Further, the SAB panel noted that “The draft IRIS document stated that the dose-response data from Wasserman et al. (2014) were not appropriate for RfD derivation because of the “nonlinearity” of the dose-response relationship (p. 4-56, lines 17 and 30; Figure C-53), and the charge question states that there is “strong nonlinearity.” However, it is unclear that this is a scientifically supportable rationale for exclusion of this study, since a linear relationship is not required for data used in dose-response evaluation, and many datasets used as the basis of PODs and RfDs are not linear.” The SAB panel then provided numerous responses to the rationales that EPA provided for not deriving an RfD on the Wasserman et al. (2014) study (see full report for details). Ultimately, the SAB panel report stated “It would be appropriate and informative for EPA to identify the dose levels (e.g., LOAEL and/or NOAEL) at which neurodevelopmental cognitive effects occur and to also, if possible, develop a candidate RfD for these effects. This evaluation could potentially consider both the U.S. study (Wasserman et al., 2014) and the Bangladeshi study (Wasserman et al., 2004), for which EPA obtained individual exposure and response data and covariates from the authors, as well as any other studies that EPA may identify as appropriate after consideration of the SAB’s recommendations. An RfD for neurodevelopmental effects would be useful for comparison with the RfDs for other endpoints (see response to charge question 9 below), even though it might not be considered for use as the final RfD due to greater uncertainty than for the other candidate RfDs. It would provide 39 information about whether the final RfD based on another endpoint (e.g., DCS) is protective of all neurodevelopmental outcomes, which would inform the need for application of a database uncertainty factor (UFD) to protect for potentially more sensitive effects, as discussed further in the response to Charge Question 8a.”

Regarding the approach used to derive an RfD for DCS and diabetes endpoints, the SAB panel report states “Regarding the BMD calculations that are relevant to both DCS and diabetes, the EPA needs to clarify and provide more support for the methods used to calculate the BMD and BMDL.” and “The EPA should explain the basis of these equations in a manner that is understandable to scientists unfamiliar with the statistical approaches used in this assessment.”

Regarding DCS, the SAB panel report states “The EPA should reconsider the endpoint used for DCS. The SAB believes that IHD incidence (both fatal and non-fatal events) or IHD mortality (fatal events) is preferable to CVD incidence as the basis for the RfD because IHD is a well-defined endpoint while CVD may include several different diseases and may not be consistently defined among studies (see response to charge question 3a). Additionally, as discussed in more detail in the response to charge question 9, it is not clear that incidence is preferable to fatalities as the basis for the RfD for DCS, and EPA should consider the benefits and limitations of using incidence versus fatalities. Selecting IHD mortality as the key outcome could be easily justified as it is an important outcome of severity and is clearly identified in the population and in research studies. The number of studies available could play a role for selecting IHD incidence or IHD mortality as the key heart disease outcome to select for the dose-response meta-analysis and derivation of the BMDL_05_. Also, the acronym DCS should be removed from this portion of the document because it causes confusion about what endpoint is being discussed. EPA should also reconsider the choice of a BMR of 5% rather than 1% for IHD incidence (or IHD mortality) and CVD incidence. The draft document (p. 4–59, paragraph beginning on line 28) states that a BMDL_05_ rather than a BMDL01 was used because clinically diagnosed type II diabetes, CVD, and IHD are not frank effects that “warrant a lower BMR [than 5%] on the basis of severity.” However, CVD and IHD incidence include both fatal and non-fatal occurrences of these diseases, and mortality is unquestionably a frank and severe effect, which could favor the focus on IHD mortality instead of IHD incidence.”

Regarding diabetes, the SAB panel report states “The SAB agrees with the approach used by the EPA to calculate the BMDL for diabetes, including an extra risk of 5%.”

Regarding birth weight, the SAB panel stated “Regarding the use of a single-study approach (vs. a combined data approach as was used for other non-cancer outcomes), generally, the SAB understood the rationale provided as to why a single study approach was used and agreed that it was clearly explained that it was the only study which utilized a dose metric based on drinking water concentrations (expressed as μg/L). Other studies which used blood, urine, or drinking water exposure (expressed as μg/day) were excluded because no PBPK models for converting biomarker metrics were validated for pregnant women. While this rationale was generally acceptable from an analytical perspective (e.g., it was the only metric readily suitable for use in dose-response), it was not found to be sufficient for the purposes of risk assessment in the context of describing if or why the study was representative or protective for this outcome relative to the overall evidence base.”

Further, the SAB panel report stated “As has been discussed for other outcomes, use of human data is preferred for dose-response modeling. The human data for decreased birthweight are sufficient to support the conclusions for dose-response presented in the draft document. Specifically, as stated in the charge question, the point of departure (BMDL_05_) for the RfD is based directly on the linear regression slope reported in Kile et al. (2016). However, information from other study types that characterize MOA, such as the studies discussed on p. 3-96–3-97, could be considered to improve the plausibility, confidence, and protectiveness of the RfD. The SAB also finds that the potential for threats to both internal and external validity had not been adequately assessed via critical appraisal, and, given such, the rationale for relying on this study requires additional explanation.”

Ultimately, the panel report emphasized that “From the modeling perspective, the use of a single study to derive the BMDL is justified since that was the only study with data that reported drinking water exposure levels in μg/L. Studies which used blood, urine, or drinking water exposure (expressed as μg/day) were excluded because no PBPK models for converting biomarker metrics were validated for pregnant women. The SAB finds that the use of the hybrid approach that harmonizes binary and continuous outcome BMRs was reasonable, as was the use of a 5% BMR level instead of 1% since birthweight is not a severe developmental effect.

The SAB panel’s tiered comments on Charge Question 7 were:

- 8 Tier 1 Recommended Revision
- 16 Tier 2 Suggested Revisions
- 4 Tier 3 Future Considerations

#### Tier 1 Recommendations for Charge 7

[underlined: SAB Recommendation (1 of 9 Tier 1 for Charge 7):] EPA should reconsider whether uncertainties related to socioeconomic and ethnic differences preclude the use of Wasserman et al. (2004) and Wasserman et al. (2014) for RfD development and consider whether these factors may be accounted for by application of a UFH for intraindividual variability.

[underlined: EPA Response:] With respect to neurocognitive effects, the ability to convert maternal urinary tAs concentrations to drinking water exposures resulted in a new set of neurocognitive studies considered for dose-response in the revised assessment (see Section 4.5). In brief, the revised study selection workflow for developmental neurocognitive effects now considers as a primary exclusion criterion whether a study controlled for smoking (i.e., through controlling for confounding due to smoking in the statistical models employed, reporting that the study participants were not smokers, or some other approach). Given this exclusion criterion, the Wasserman et al. (2004) and Wasserman et al. (2014) studies did not make it past this step in the study selection workflow because they did not control for maternal smoking or second-hand smoke in their analysis. This obviates the need to discuss why a Bangladeshi population is appropriate for single-study POD derivation for birth weight (i.e., Kile et al. (2016)) but not developmental neurocognitive effects (i.e., Wasserman et al. (2014)), especially in the light of the new meta-analysis for birth weight effects. Ultimately, when considering developmental neurocognitive studies that made it through the revised study selection workflow, four studies are now considered for use in POD derivation (as discussed in Section 4.5): Vahter et al. (2020), Soler-Blasco et al. (2022), Signes-Pastor et al. (2022), and Chen et al. (2023). Vahter et al. (2020) was not selected for POD derivation due to its reporting of regression coefficients for quintiles of exposure and not for the entire dose range in the study. The remaining three studies were included in a meta-analysis to estimate a pooled effect on general IQ scores. Signes-Pastor et al. (2022) is a high confidence study conducted in an U.S. population that creatinine-adjusted maternal urinary tAs concentrations for urinary dilution, controlled for smoking by including maternal cotinine concentrations in statistical models, and observed an inverse association of full scale IQ (at various ages using multiple testing approaches) with maternal urinary tAs concentrations. Chen et al. (2023) is a medium confidence study conducted in China that controlled for urinary dilution via specific gravity adjustment and controlled for active smoking by excluding smokers and passive smoking by including this covariate as a confounder in statistical models, and observed a borderline statistically significant inverse relationship IQ (age 2, Bayley Scales of Infant Development; BSID). Soler-Blasco et al. (2022) is a high confidence study conducted in a US-relevant population (Spain) that creatinine-adjusted maternal urinary tAs concentrations and controlled for smoking and observed largely null associations with full scale IQ (age 5, McCarthy Scales of Children’s Abilities; MSCA). Given that two of these studies were conducted in U.S. populations, the use of a meta-analysis in this context minimizes concerns for the generalizability of the results to U.S. populations.

Briefly, given that all three studies in the neurodevelopmental meta-analysis estimated beta coefficients using log2 transformed urinary concentrations, the meta-analysis was conducted using the study-reported betas to minimize the need for re-expression to the natural scale. The pooled beta coefficient was estimated to be 1.46 IQ points per log2(µg/L) maternal urinary tAs concentration (95% CI: −3.03−0.11). Re-expression to the natural scale resulted in a beta coefficient of −0.19 IQ points per μg/L maternal urinary tAs concentration (95% CI: −0.39, 0.01). A candidate point of departure for decreased IQ using the re-expressed pooled beta was estimated as 0.315 µg/kg-day using the methods described in Section C.3.1.

[underlined: SAB Recommendation (2 of 9 Tier 1 for Charge 7):] EPA should reanalyze the dose-response relationship in Wasserman et al. (2014) and consider whether the dose-response relationship, particularly in the lower dose range (<20 µg/L), can be used as the basis for POD development.

[underlined: EPA Response:]Wasserman et al. (2014) is no longer considered for POD derivation in the revised assessment given its exclusion due to the study not adequately accounting for maternal smoking or second-hand smoke in its statistical analyses. Instead, a meta-analysis of three neurodevelopmental studies is used for POD derivation (see above EPA response).

[underlined: SAB Recommendation (3 of 9 Tier 1 for Charge 7):] EPA should consider whether the approach for the proposed RfD for birth outcomes, which uses U.S. data to interpret adversity from a study in a non-U.S. population, is also applicable to neurodevelopmental effects. If it is concluded that this approach is not applicable to neurodevelopmental effects, a rationale should be provided as to why it is appropriate for birth outcomes but not for neurodevelopmental outcomes.

[underlined: EPA Response:] The same approach for BMD estimation used for birth weight effects is now used for developmental neurocognitive effects. The meta-analysis of neurodevelopmental studies provides a pooled linear regression that can be used to estimate a BMD and BMDL (see response to the 1st Tier 1 recommendation).

[underlined: SAB Recommendation (4 of 9 Tier 1 for Charge 7):] Additional information should be provided about the rationale for exclusion of the 52 studies of neurodevelopmental behavioral effects considered (except for Wasserman et al. (2004) and Wasserman et al. (2014)). This discussion should include which criteria were not met for each excluded study. It should also discuss whether the two studies selected for dose-response analyses were the most sensitive and/or where the magnitude of the effects reported in those two studies fell relative to the overall evidence base.

[underlined: EPA Response:] EPA has implemented a revised study selection workflow for developmental neurocognitive effects that considers a number of inclusion/exclusion criteria in order to identify studies suitable for POD derivation. See Section 4.5 for details of this study selection workflow, including a diagram displaying the steps in the process and details on inclusion/exclusion criteria and which studies met or failed those criteria. Moreover, in response to a Tier 2 recommendation (below), EPA conducted a targeted search of more recently published literature to determine if other studies evaluating neurodevelopmental health impairments associated with iAs exposure could be included in the assessment. Briefly, out of the 64 developmental neurocognitive studies considered, four studies were considered for potential use in POD derivation (as discussed in Section 4.5): Vahter et al. (2020), Soler-Blasco et al. (2022), Signes-Pastor et al. (2022), and Chen et al. (2023). Vahter et al. (2020) was not selected for POD derivation due to its reporting of regression coefficients for quintiles of exposure and not for the entire dose range in the study. The remaining three studies were included in a meta-analysis to estimate a pooled effect on general IQ scores (see response to the 1st Tier 1 recommendation).

[underlined: SAB Recommendation (5 of 9 Tier 1 for Charge 7):] Explain, in language accessible to a general scientific audience, the basis for the BMD and BMDL equations used for DCS and diabetes.

[underlined: EPA Response:] The revised assessment provides a more thorough and accessible explanation of the methodology used to estimate BMDs and BMDLs for dose-response meta-analysis non-cancer outcomes (i.e., IHD and diabetes) in Section 4.6 and C.1.3.

[underlined: SAB Recommendation (6 of 9 Tier 1 for Charge 7):] Conduct analyses of both IHD mortality (fatal events only) and IHD incidence (both fatal and non-fatal events) instead of CVD incidence as the DCS endpoint for computation of the RfD.

[underlined: EPA Response:] The revised assessment now only considers IHD (with the endpoint consisting of both studies that include only incident cases or both incident and fatal cases of IHD), diabetes, birth weight, and developmental neurocognitive effects for estimation of non-cancer candidate values and the final non-cancer RfD. IHD mortality was not considered for RfD derivation given there were only two available studies for this endpoint and EPA determined that three studies are required for the hierarchical Bayesian dose-response meta-analysis methods used in the assessment (see above for EPA’s response to SAB’s recommendation (SAB Recommendation (1 of 1 Tier 1 for Charge 3.a) and suggestion (SAB Suggestion (11 of 11 Tier 2 for Charge 4.b)). Among the outcomes considered for RfD derivation, diabetes and IHD were selected as the outcomes to derive the final RfD given they resulted in the lowest candidate value across all considered outcomes when rounded to one significant digit: 0.06 µg/kg-day.

[underlined: SAB Recommendation (7 of 9 Tier 1 for Charge 7):] A BMR of 1% instead of 5% (i.e., BMDL_01_ instead of BMDL_05_) should be considered in light of the severity (substantial incidence of mortality) of IHD.

[underlined: EPA Response:] In the revised assessment, a more detailed consideration of the study-specific results (e.g., individual cases) in the dose-response analyses was used to select the BMR for the IHD (incident and fatal cases) endpoint. The specifics of this revised approach and explanations on its implementation are outlined below, but briefly, the new approach to defining the BMR for IHD applied a BMR of 1% extra risks to fatal case and a BMR of 5% extra risk to incident cases of IHD in the studies modeled.

It is true that for some studies, the definition of IHD includes both incident and fatal cases of IHD. However, for other studies, the case definition of IHD outcomes includes only incident cases. For example, for the IHD outcome, there are five studies total included in the dose-response meta-analysis. Two of these studies, Wade et al. (2015) and Wu et al. (2010), did not include fatal cases of disease. Other studies, Moon et al. (2013), Chen et al. (2013), and James et al. (2015), did include incident and fatal cases of disease, but incidence cases are expected to dominate, particularly at lower exposure levels. In the Moon et al. (2013) study, the number of incident and fatal cases and fatal only cases are reported, so it is possible to investigate the proportion of incident cases in each exposure group. This is the only study on iAs and IHD that includes this breakdown. For example, there are 202, 206, 197, and 241 cases of incident and fatal cases of IHD in the individual exposure groups used in Moon et al. (2013), while there are only 68, 67, 87, and 119 cases of fatal IHD in those same exposure groups. Therefore, the proportion of incident cases of IHD across the exposure groups is approximately 60%, compared to 40% for fatal cases. While Chen et al. (2013) and James et al. (2015) do not separately report incident plus fatal cases and fatal only cases, the revised analysis assumes that the same pattern of more incident cases than fatal cases holds for these studies as well. Thus, it is possible to calculate a weighted (by sample size) BMR across all studies that accounts for the application of a BMR = 1% extra risk for fatal cases and a BMR = 5% extra risk for incident cases (when using the 60% incidence/40% fatal split as observed in the Moon et al. (2013) study). Doing so results in a BMR = 3.86% ~ 3.9% extra risk. A supplemental analysis was conducted in which the BMDL resulting from this analysis (for incidence and fatal cases) was compared to BMDLs calculated for fatal-only studies (using a BMR of 1% extra risk) and incidence-only studies (using a BMR = 5% extra risk). Note that these supplemental BMDL derivations were based on dose-response meta-analyses consisting of only two studies and therefore do not comport with EPA’s statement that the minimum number of studies to base a dose-response meta-analysis on is three. Therefore, these supplemental analyses are only used for comparative purposes and were not considered for point of departure derivations in the main assessment. The BMDL_01_ for fatal-only studies was 0.1399 µg/kg-d, compared to the BMLD_05_ of 0.2271 for incidence-only studies and the BMDL_01,05_ of 0.1707 for incidence and fatal studies. Thus, consideration of a lower BMR = 1% for fatal-only studies did not result in a BMDL substantially lower than the main analysis using a BMR = 3.9% and incidence plus fatal IHD studies (0.1399 µg/kg-d vs. 0.1707 µg/kg-d, a 22% difference). Using a lower BMR of 1% extra risk for the incidence and fatal IHD analysis would result in a lower BMDL; however, applying a BMR reserved for frank effects to studies solely comprised of or consisting of a substantial proportion of incidence cases of IHD (i.e., not a frank effect) was not deemed appropriate. Therefore, in the revised assessment, a BMR of 3.9% extra risk was determined to be the most appropriate BMR for IHD (i.e., studies consisting of incident and/or fatal cases of IHD). The justification for the selection of the BMR for IHD has been updated in the revised assessment (see Section C.1.3).

A further supplemental analysis was conducted using an alternative breakdown of incident vs. fatal cases of IHD, given the 60% incident/40% fatal breakdown in Moon et al. (2013) is likely a conservative assumption given the increased susceptibility of the study population studied in Moon et al. (2013). An 80% incident/20% fatal breakdown, based on estimates of the general U.S. population (https://jamanetwork.com/journals/jamanetworkopen/fullarticle/2728009), was used to estimate an alternative weighted BMR of 4.4% for IHD. Using this BMR resulted in a slightly higher POD (0.1910 µg/kg-day). However, as the proportions vary depending on the study population (e.g., sex; age; ethnicity), methods and definitions used, and timing (generally, with fewer fatal cases over time, attributable in part to improvements in medical procedures and medication), the actual study-specific proportions remain an uncertainty, and use of the proportions observed in the Moon et al. (2013) study were retained for the main analysis. Ultimately, use of a BMR of 3.9% extra risk vs. 4.4% extra risk result in identical candidate values when rounded to one significant digit, so uncertainty regarding the most appropriate BMR for IHD does not substantially impact the derivation of the RfD.

[underlined: SAB Recommendation (8 of 9 Tier 1 for Charge 7):] Provide rationale for the selection of the Kile et al. (2016) study beyond the suitability of the dose-metric, and specifically the adequacy of this single study for determining a point of departure protective for this outcome. Such rationale should be provided both in the selection of the candidate studies as well as carried through to the descriptions of confidence in the point of departure as well as uncertainties in the assessment.

[underlined: EPA Response:] For the external peer review draft of the iAs assessment, EPA only considered the Kile et al. (2016) study because it was the only birth weight study that used drinking water concentrations as the dose-metric. At the time of the external peer review draft, EPA was unaware of a method to convert maternal tAs urinary concentrations into drinking water concentrations or daily intake values. EPA has determined that the Gilbert-Diamond et al. (2016) study, suggested by the SAB panel, provides an approach for converting maternal urinary tAs concentrations (adjusted for urine dilution or not) into daily drinking water exposure in units of µg/day inorganic As. As such, studies of pregnancy outcomes (i.e., birth weight) that used maternal urinary tAs as the dose metric can now be considered for inclusion in dose-response analyses for these outcomes. Several studies that used maternal urinary tAs as the dose metric made it through EPA’s study selection process and were considered for a meta-analysis in the revised assessment. These studies (Rahman et al., 2009; Liu et al., 2018; Liao et al., 2018; Laine et al., 2015; Goodrich et al., 2019; Gilbert-Diamond et al., 2016) primarily reported beta coefficients that were estimated using log-transformed (using various bases: log10, loge, or log2) urinary tAs concentrations and thus needed to be re-expressed to the normal scale before estimating a pooled beta (see Section C.2). Briefly, the pooled beta coefficient was estimated to be −1.28 g (95%CI: −2.05, −0.52) birth weight per (µg/L) increase in maternal urinary tAs concentration. A candidate point of departure for decreased birthweight using the pooled beta was estimated as 1.4 µg/kg-day using the methods described in Section C.2. Note that the revised assessment also includes a POD estimated using the single Kile et al. (2016) based on the re-expressed beta coefficient from that study: −3.91 g per µg/L (95% CI: −5.13, −2.7). The POD derived using the results of the meta-analysis was 1.4 µg/kg-day compared to the POD of 0.237 µg/kg-day when using the Kile study results alone. Given the Kile study is retained in the dose-response analysis, additional information has been added to the revised assessment pertaining to the suitability of the Kile et al. (2016) study for POD derivation and any relevant information has been carried forward through to descriptions of confidence in the study and quantification approaches and discussion of uncertainty in the analysis, if applicable. Ultimately, the POD of 0.237 µg/kg-day based on the Kile et al. (2016) study was selected as the osRfD for birth weight.

[underlined: SAB Recommendation (9 of 9 Tier 1 for Charge 7):] Provide a description and rationale for the inconsistency in use of U.S. based comparisons to adjust/interpret data based on the Bangladeshi population for the pregnancy outcome (vs. neurodevelopmental).

[underlined: EPA Response:] Given the identification of the Gilbert-Diamond et al. (2016) study and the ability to convert maternal urinary tAs concentrations into drinking water exposures, EPA is no longer constrained to studies of pregnancy outcomes or neurocognitive effects that used drinking water concentration or exposure as the dose metric. The impact of this on pregnancy and neurocognitive outcomes is discussed above (see above responses to the 7th and 1st Tier 1 recommendations, respectively).

#### Tier 2 Suggestions for Charge 7

[underlined: SAB Suggestion (1 of 15 Tier 2 for Charge 7):] Regarding potential lead exposure in Wasserman et al. (2014), EPA should discuss whether there is reason to expect that exposure to lead and iAS would be positively correlated in this study and that EPA clarify why lack of information on lead exposure was not considered in evaluating bias in this study.

[underlined: SAB Suggestion (2 of 15 Tier 2 for Charge 7):] EPA should clarify why “relatively low” exposures in Wasserman et al. (2014) potentially limited the ability to detect effects at higher doses, since this statement appears to be inconsistent with the exclusion of other studies because exposure was above the range relevant to the U.S. population.

[underlined: SAB Suggestion (3 of 15 Tier 2 for Charge 7):] EPA should clarify whether lack of information on birth weight is a relevant concern in evaluation study bias for Wasserman et al. (2014).

[underlined: EPA Response (to Tier 2 Suggestions 1, 2, and 3 of 15 for Charge 7):]Wasserman et al. (2014) is no longer considered for POD derivation in the revised assessment given its exclusion due to the study not adequately accounting for maternal smoking or second-hand smoke in its statistical analyses.

[underlined: SAB Suggestion (4 of 15 Tier 2 for Charge 7):] EPA should discuss whether generalizability was used as a criterion for study selection. If so, the rationale and/or acknowledgment of use of generalizability as a criterion should be provided.

[underlined: EPA Response:] Generalizability of studies was not an explicit, stand-alone study selection criterion for determining what studies were suitable for meta-analysis, but was sometimes considered in the context of other selection criteria. Given that the intent of the dose-response analyses was to identify a robust set of studies from multiple populations, generalizability was not seen as a critical factor. While studies from the United States or populations from geographic areas expected to be similar to populations in the United States (i.e., European countries, etc.) were preferred, studies from other populations that may differ in important characteristics (nutrition, exposure, etc.) compared to the United States were not automatically excluded from dose-response analyses unless other specific criteria were also not met. For example, generalizability was considered in the context of exceedingly high exposure-populations, e.g., studies from Southwest Taiwan were excluded. Including a broad set of studies representative of diverse populations in the dose-response analysis is a strength of the meta-analysis approach used in the assessment.

[underlined: SAB Suggestion (5 of 15 Tier 2 for Charge 7):] EPA should identify the dose levels (e.g., LOAEL and/or NOAEL) at which neurodevelopmental cognitive effects were observed and develop a candidate RfD for these effects if possible. Wasserman et al. (2014) and Wasserman et al. (2004), and other studies that EPA may identify as appropriate should be considered for RfD development.

[underlined: EPA Response:] Identification of a NOAEL or LOAEL is no longer applicable given that the meta-analysis of three neurodevelopmental studies is now being used to derive a POD for developmental neurocognitive effects (see response to the 1st Tier 1 recommendation).

[underlined: SAB Suggestion (6 of 15 Tier 2 for Charge 7):] If a BMD/BMDL cannot be developed from Wasserman et al. (2014) data, EPA should consider development of an RfD based on this LOAEL, or at a minimum, comparison of this LOAEL to the PODs for other non-cancer effects to determine whether neurocognitive effects are more sensitive.

[underlined: EPA Response:] See above; the Wasserman et al. (2014) study is no longer considered for POD derivation. Instead, the meta-analysis of three neurodevelopmental studies is used.

[underlined: SAB Suggestion (7 of 15 Tier 2 for Charge 7):] If it is determined that neurodevelopmental effects are a sensitive outcome but the RfD for these effects is too uncertain for use as the final RfD, EPA should consider application of a database uncertainty factor (UFD) to protect for potentially more sensitive neurodevelopmental effects.

[underlined: EPA Response:] A POD and candidate organ-specific value are now derived for developmental neurocognitive effects using the meta-analysis of three neurodevelopmental studies. This value was considered in selecting the UFD = 1 in the revised assessment, as described in Section 4.6.2.

[underlined: SAB Suggestion (8 of 15 Tier 2 for Charge 7):] The more recently published literature that identifies neurodevelopmental health impairments associated with iAs exposure should be evaluated.

[underlined: EPA Response:] EPA conducted an updated targeted literature search for developmental neurocognitive effects in August 2024 (see Section 1.6.1.). The literature search followed the methods described in the external review draft, with details provided in Section 1.6.1 (see Table 1-2 for the PECO criteria) and Appendix B of the protocol. The revised study selection workflow for developmental neurocognitive effects was applied to all identified high and medium confidence studies (61 in total). Studies identified as studies for potential inclusion by the SAB (including Vaidya et al. (2023) and de la Ossa et al. (2023)) were both captured in the 2024 literature update, However, neither of these studies made it through the revised study selection workflow as they either measured tAs in the urine or blood of children or adolescents. Currently, EPA is not aware of an approach to convert child/adolescent urinary or blood tAs concentrations into drinking water concentrations or exposure (note: while the revised assessment now applies a method for converting maternal urinary tAs, no parallel methods for converting urinary tAs in children or adolescents were identified). Of the total number of neurodevelopmental studies considered for dose-response selection, four studies made it through the selection workflow (see above response to the 5th Tier 1 recommendation).

[underlined: SAB Suggestion (9 of 15 Tier 2 for Charge 7):] Revise the presentation of the odds in the BMD and BMDL equations to provide a better representation of the intended quantities, and which is more in line with standard epidemiological and biostatistical notation.

[underlined: EPA Response:] As part of this comment and the above comment, the equations for calculating BMDs and BMDLs for IHD and diabetes have been revised so that standard statistical notation is used to represent the odds of disease at the dose corresponding to specific extra risks.

[underlined: SAB Suggestion (10 of 15 Tier 2 for Charge 7):] Define extra risk (in words and via an equation) in the section containing the BMD and BMDL.

[underlined: EPA Response:] The revised assessment now includes a definition of extra risk in the text and an equation showing its mathematical calculation.

[underlined: SAB Suggestion (11 of 15 Tier 2 for Charge 7):] The SAB panel recommends dropping the DCS acronym.

[underlined: EPA Response:] EPA interprets this SAB comment in the context of the fuller discussion on pages 41–42 of the SAB report, where the panel recommends that “… the acronym DCS should be removed from this portion of the document because it causes confusion about what endpoint is being discussed.” Therefore, in the discussion of the derivation of the RfD, the acronym DCS is dropped where appropriate to mitigate confusion. The acronym DCS is not removed globally from the revised assessment.

[underlined: SAB Suggestion (12 of 15 Tier 2 for Charge 7):] Review Tables C-81 and 4-17, 4-21, and 4-22 to ensure the correct BMD and BMDL values are reported.

[underlined: EPA Response:] The revised assessment has been cross-checked to ensure that the correct numerical values and modeling results are presented in the text and in tables.

[underlined: SAB Suggestion (13 of 15 Tier 2 for Charge 7):] In Table 4-11, provide the correct posterior mean of the slope for the Grau-Perez et al. (2017) study.

[underlined: EPA Response:] The revised assessment has been cross-checked to ensure that the correct numerical values and modeling results are presented in the text and in tables.

[underlined: SAB Suggestion (14 of 15 Tier 2 for Charge 7):] Qualitatively address potential uncertainties in the dose-response assessment introduced by utilizing the CDC Wonder database.

[underlined: EPA Response:] Use of the CDC Wonder database should decrease uncertainty in the dose-response analysis of birth weight. The CDC Wonder database contains the full natality file for the United States, from which EPA estimated the mean birth weight (with accompanying standard deviation) and the percentage of US births that fall below the clinical definition of adversity (i.e., below 2,500 grams). The number of births used to generate these values used for BMR definition exceeded 3.7 million. One uncertainty in the use of the Wonder site data to define the BMR for birth weight is its use in conjunction with a beta reported in non-US studies (e.g., the Kile study). However, EPA is not aware of a queryable database of Bangladeshi birth weights (or for Mexico or Taiwan) and the use of the hybrid approach is deemed more suitable than defining the BMR based on a percent change in mean birth weight. A brief discussion of the uncertainties and benefits of using the CDC Wonder database has been added to the revised assessment.

[underlined: SAB Suggestion (15 of 15 Tier 2 for Charge 7):] Clearly describe the process to re-express β and BMDL calculations (described in comments; p. 4-52, 4-53).

[underlined: EPA Response:] The explanation of the methodology used to re-express study-specific beta coefficients and use those beta coefficients (and their 95th upper bound) to calculate BMD (and BMDL) values has been expanded in the revised assessment.

#### Tier 3 Future Consideration Charge 7

[underlined: SAB Future Consideration (1 of 4 Tier 3 for Charge 7):] Use animal data to support the plausibility of the estimated BMDs.

[underlined: EPA Response:] EPA appreciates this future consideration from SAB. In the case of arsenic, because experimental laboratory animals have a higher rate of arsenic metabolism and urinary clearance than humans (Vahter, 1999a; Vahter and Concha, 2001; EFSA, 2009; Douillet et al., 2023; ATSDR, 2007) animals are often dosed at arsenic concentrations that are of questionable environmental relevance (i.e., ppm vs. ppb). In addition, the duration of the available animal studies are limited to short term or subchronic duration studies. This limits the utility of the current data coming from such models to provide quantitative human health or use in developing chronic toxicity values (EFSA, 2009; ATSDR, 2007). EPA is also aware that certain humanized and specialized mouse models may be able to provide information at more environmentally relevant levels of arsenic, e.g., the Apoe -/- and p47PHOX knock-out mice for cardiovascular related endpoints (Srivastava et al., 2009; Simeonova et al., 2003; Makhani et al., 2018; Lemaire et al., 2011) and capillarization and vessel remodeling (Straub et al., 2008). While additional studies may prove informative to future assessments, the revised IRIS iAs assessment maintains that the currently available animal data do not provide support for the plausibility of the estimated BMDs (or any PODs).

[underlined: SAB Future Consideration (2 of 4 Tier 3 for Charge 7):] Use the results from the Bayesian meta-regression to generate a complete posterior distribution for the BMD.

[underlined: EPA Response:] In the revised assessment, given the use of the logistic-power model to model IHD and diabetes, benchmark doses were obtained by solving the equations listed in Section C.1.3 for each sampled pair of β and q from the full posterior obtained during the hierarchical modeling. The BMD is then set to the median of that posterior of BMD samples and the BMDL is set as the 5th percentile of that distribution.

[underlined: SAB Future Consideration (3 of 4 Tier 3 for Charge 7):] Consider using animal data and/or mechanistic data (MOA) to support and improve confidence and plausibility of the selected points of departure at low levels of iAs exposure when dose-response is based on observational studies in humans.

[underlined: EPA Response:] Although the iAs assessment focused on epidemiological evidence, the assessment discusses supporting information from animals and mechanistic model systems (see Section 3.2.3). The studies described in Section 3,2.3 suggest a variety of pathways by which arsenic exposure could affect the placenta in ways that reduce fetal growth and lead to low birth weight; however, this section also describes notable uncertainties in the interpretation of these data that reduce their utility as compared to the direct evidence in exposed humans.

[underlined: SAB Future Consideration (4 of 4 Tier 3 for Charge 7):] Quantitatively assess the potential impact and sensitivities of residual/uncontrolled biases in observational data, as well as impact of use of surrogates (e.g., application of U.S. standard to other geographies) or related aspects when deviations or amendments to author-reported data are required for dose-response analyses.

[underlined: EPA Response:] EPA appreciates the comment and will consider this consideration as it continues to identify opportunities to advance analysis approaches for epidemiological evidence. Specific to the iAs meta-analyses, the revised assessment includes adjustments to both the exposures Allen et al. (2020a) and the responses Allen et al. (2020b) reported by authors. Author reported exposures are converted to a common ug/kg-day unit of dose. Sensitivity analyses performed by EPA for these dose conversions are discussed in Section C.1.1, in the Section titled “Treatment of Dose Uncertainty” and also in Section C.1.2, in the “Sensitivity Analysis” sections for each of the endpoints for which meta-analyses were performed. As discussed in Section C.1.1, in the section titled “Adjusting for Covariates,” response data reported by authors are converted to “effective counts” to create a set of counts for use in the EPA meta-analysis that are intended to reflect only the effect of arsenic and allow for the combination of cohort and case-control studies in a meta-analysis.

### F.6.2 Public Comments on Non-Cancer RfD Candidate Values (Charge Question 7)

[underlined: Public Comment:] One commenter (Dr. Kan Shao) made multiple comments on the lifetime extra risk plots. First, this commenter stated that the input data used in BMD modeling were not dose-response data directly collected from toxicological or epidemiological studies and instead these data are estimated extra risks at various exposure levels based on the lifetable approach. This commenter specifically objected to the fitting of statistical models to fit data already estimated from dose-response models, that the number of points in the lifetime extra risk plots could be arbitrarily increased or decreased, thus affecting the statistical performance of the fitted linear or polynomial trendline. This commenter also thought it inappropriate to estimate extra risk values below the background exposure level and then use them in BMD modeling. This commenter also noted that only linear and polynomial dose-response models were used for the lifetime extra risk trendlines and questioned why more flexible (Exponential 5 or Hill models) were not also applied. This commenter further claimed that the apparent linear nature of the lifetime extra risks was due to use of the logistic slope in the lifetable approach, which implicitly assumed linearity. The commenter noted that the modeling algorithm used in estimation of the lifetime extra risk trendlines was not consistent with typical modeling approaches in BMD modeling. Lastly, this commenter notes that the data in the lifetime extra risk plots only consist of dose and a response level and do not quantify the uncertainty in the data and that the BMDL05 marked on the graph is not a statistical lower bound of the BMD estimate.

[underlined: EPA Response:] The lifetime extra risk plots are included in the assessment to provide a visual demonstration of how lifetime extra risks for various outcomes vary across a wide exposure range. The commenter is correct that the lifetime extra risks (represented by black points in the graphs) are the output of the lifetable analysis. However, even though the lifetime extra risks for CVD outcomes and diabetes in the external peer review draft of the assessment displayed an BMDL_05_ value, this value was not derived by fitting a statistical dose-response model to the estimated lifetime extra risks. The BMDs and BMDLs for IHD and diabetes were estimated using the methods described in Section 4.6 and C.1.3. Briefly, for each ordered pair of the logistic slope (β) and power parameter (q) in the posterior distribution generated from the dose-response meta-analysis, the iteration-specific BMD was calculated as B M D = root((In ( O R ))/(β), q) , where ln(OR) is defined as the ratio of probability of disease at 5% and 0% extra risk. The final BMD is set as the median of the full posterior distribution and the BMDL as the 5th percentile of the posterior distribution. To avoid confusion about how the BMDs and BMDLs were estimated, the BMDL_05_ values have been removed from the lifetime extra risk plots. Also, regarding the comment that the number of points could be arbitrarily increased or decreased to impact statistical performance, sensitivity analyses were conducted to show that the estimated trendline equation does not appreciably change with decreased or increased point values (see sensitivity analysis results in Sections C.1.2 for IHD and diabetes). In brief, varying the number of lifetime extra risks used to generate the linear and polynomial trendlines has almost no impact on the estimation of the trendline equations.

The trendlines in the lifetime extra risk plots do not represent “dose-response” modeling and thus the comment about applying additional models (e.g., Exponential 5 or Hill models) is moot. The assessment has been revised to make clear that the trendlines were not used to generate BMD or BMDL values. Further, the lifetable approach does not just use the logistic slope parameter, it uses the logistic slope parameter and the power parameter in the logistic-power model non-linear equation to estimate lifetime extra risks. Thus, the lifetable approach does not just use the logistic slope and, given the non-linear nature of the logistic-power model, does not explicitly or implicitly assume linearity.

The BMDL_05_ included in the non-cancer extra risk lifetime plots was estimated using the methods described in Section 4.6 and only included on the graph to provide visual context for the value of the BMDL vs. the full range of lifetime extra risks. The trendlines provided allow users to calculate approximate lifetime extra risks using a simple equation rather than running the lifetable analyses themselves to generate an exact lifetime extra risk estimate. Additionally, it is not correct that the trendlines do not quantify the uncertainty in the data as the plots present two dashed lines that correspond to the mean and 95% upper bounds of the lifetime risk (i.e., calculated using the range of mean lifetime extra risk values or the range of 95% upper bound lifetime extra risk values) and thus do provide information on uncertainty of the Bayesian hierarchical dose-response meta-analysis and lifetable modeling. Lastly, the BMDL_05_ itself also is a statistical lower bound and quantifies the uncertainty in the BMD estimation as described in Sections 4.6 and C.1.3. The assessment has been revised to make all of these points clearer.

[underlined: Public Comment:] One reviewer (Students of Johns Hopkins Bloomberg School of Public Health Risk Sciences and Public Policy Institute) requested clarification on the data choices for non-cancer outcomes.

[underlined: EPA Response:] The rationale for prioritizing certain non-cancer outcomes was presented in the protocol for the assessment (Appendix A), which was reviewed by NASEM in 2019 (NASEM, 2019). The study selection section describing which studies were considered for dose-response analyses and inclusion/exclusion criteria has been substantially revised in the assessment (see Sections 4.3.1, 4.4, and 4.5). For each outcome considered for dose-response, the number and identity of studies that fail to meet the study selection inclusion criteria are identified in the text and accompanying figures with justifications provided.

[underlined: Public Comment:] One commenter (Students of Johns Hopkins Bloomberg School of Public Health Risk Sciences and Public Policy Institute) agreed with EPA’s approach to determine that the Wasserman et al. (2014) study was not appropriate for development of a neurodevelopmental candidate value but recommended considering other sources of data for the development of an RfD for neurodevelopmental effects.

[underlined: EPA Response:] The dose-response analysis of neurodevelopment effects has been revised, including conducting a targeted search update for recently published neurodevelopmental epidemiological studies that could be used to support utilizing a dose-response meta-analysis approach, as suggested by the SAB panel (9 of 16 Tier 2 for Charge 7). As described above in the response to another SAB recommendation (1 of 9 Tier 1 for Charge 7), four neurodevelopmental studies made it through the revised study selection workflow: Vahter et al. (2020), Soler-Blasco et al. (2022), Signes-Pastor et al. (2022), and Chen et al. (2023). Vahter et al. (2020) was not selected for POD derivation due to its reporting of regression coefficients for quintiles of exposure and not for the entire dose range in the study. The remaining three studies were included in a meta-analysis to estimate a pooled effect on general IQ scores. Briefly, all three studies in the neurodevelopmental meta-analysis estimated beta coefficients using log2 transformed urinary concentrations. The meta-analysis therefore was conducted using the study-reported betas to minimize the need for re-expression to the natural scale. The pooled beta coefficient was estimated to be 1.46 IQ points per log2(µg/L) maternal urinary tAs concentration (95% CI: −3.03–0.11). Re-expression to the natural scale resulted in a beta coefficient of −0.19 (95%CI: −0.39, 0.01) IQ points per μg/L maternal urinary tAs concentration. A candidate point of departure for decreased IQ using the re-expressed pooled beta was estimated as 0.315 µg/kg-day using the methods described in Section C.3.1.

[underlined: Public Comment:] One commenter (Environmental Integrity Project and Earthjustice) strongly disagreed with EPA’s decision to not derive an RfD for neurodevelopmental effects pointing to the consistent evidence of iAs-induced cognitive effects in numerous medium or high confidence studies. This commenter recommended that EPA guidance provides clear methods for deriving reference doses when dose-response modeling is deemed inappropriate and specifically cited EPA’s 2002 “Review of the Reference Dose and Refence Concentration Process” (U.S. EPA, 2002b) document to support identification of a NOAEL or LOAEL for the neurodevelopmental point of departure. This reviewer also specifically recommends that the Wasserman et al. (2014) study in Maine children is the best available study for neurodevelopmental toxicity and that the IQ decrements seen in the lowest dose group were appropriate for identification of a LOAEL. This commenter strongly urged EPA to revise the proposed reference dose to make it protective against neurodevelopmental toxicity.

[underlined: EPA Response:] The analysis of neurodevelopmental effects has been extensively revised. In the revised assessment, EPA conducted a meta-analysis of three neurodevelopmental studies that reported IQ decrements in children prenatally exposed to iAs and estimated a point-of-departure of 0.315 µg/kg-day using the methods described in Section C.3.1.

[underlined: Public Comment:] One commenter (Superfund Settlement Project and RCRA Corrective Action Project) noted that no files were provided on the modeling of neurocognitive effects.

[underlined: EPA Response:] All files related to the modeling of neurocognitive or neurodevelopmental effects have been provided as part of the Supplemental Materials for the final draft of the iAs assessment.

[underlined: Public Comment:] One commenter (Students of Johns Hopkins Bloomberg School of Public Health Risk Sciences and Public Policy Institute) recommended that the assessment be revised to provide further explanation why a BMR of 1% extra risk was not used to derive the non-cancer points of departure. Another commenter [University of California, San Francisco (UCSF)] stated that the dose-response analysis demonstrated that the proposed RfD is not protective of public health and that EPA’s choice of a 5% benchmark response level is too high.

[underlined: EPA Response:] The revised assessment now applies a BMR of 1% to fatal cases of IHD (see EPA response to SAB Recommendation (7 of 9 Tier 1 for Charge 7)). In addition, the rationale for the selection of a BMR of 5% for IHD incident cases has been strengthened in the revised assessment (see response to SAB Recommendation (7 of 9 Tier 1 for Charge 7 above); the rationale for the BMR of 5% for diabetes is retained in the revised assessment.

[underlined: Public Comment:] One commenter (Students of Johns Hopkins Bloomberg School of Public Health Risk Sciences and Public Policy Institute) questioned why inhalation exposures were not considered and recommended that inhalation exposure be included in the benchmark dose calculations.

[underlined: Public Comment:] In a related comment, this commenter (Students of Johns Hopkins Bloomberg School of Public Health Risk Sciences and Public Policy Institute) noted that EPA did not adequately address CVD incidence in smokers by not considering air intake as the primary method of exposure to inorganic arsenic in this population.

[underlined: EPA Response (to both Public Comments above):] It is unclear whether this commenter is recommending that inhalation toxicity values (e.g., a reference concentration, or RfC) be derived or if inhalation exposures should be included in the estimation of the assumed background exposure level of iAs. To respond to the first point, the scoping needs identified by EPA Programs and regions were focused on oral exposure; this is summarized in the Systematic Review Protocol for the Inorganic Arsenic (Appendix A). Thus, derivation of inhalation toxicity values for iAs is outside the scope of the assessment. To respond to the second point, the potential contribution of inhalation exposure to background calculations were considered as a sensitivity analysis and shown to not be impactful to the final toxicity estimates (see endpoint-specific sensitivity analysis results in Section C.1.2). Specifically, cigarette smoking has not been found to significantly increase arsenic body burden as measured by urinary arsenic levels (Marano et al., 2012).

[underlined: Public Comment:] One commenter (Students of Johns Hopkins Bloomberg School of Public Health Risk Sciences and Public Policy Institute) questioned the scientific justification of the pregnancy outcomes candidate value derivation given that it was based on a single study compared to the dose-response meta-analysis approach used for other non-cancer outcomes and recommended the inclusion of more studies in the derivation of the candidate value. This commenter further noted that the dose-response modeling for pregnancy outcomes used the hybrid definition of the benchmark response and noted that this approach is not commonly used in IRIS analyses.

[underlined: EPA Response:] EPA has evaluated a study recommended by the SAB panel (Gilbert-Diamond et al., 2016) and determined it provides an approach for converting maternal urinary total As (tAs) concentrations (both adjusted for urine dilution or not) into daily drinking water exposure (in units of µg/day inorganic As) (see EPA response to SAB Recommendation (2 of 2 Tier 1 for Charge 4.a)). As such, studies of pregnancy outcomes (i.e., birth weight) and neurodevelopmental cognition that used maternal urinary tAs as the dose metric are now considered for inclusion in dose-response analyses for these outcomes (see response to 2nd Tier 1 recommendation for Charge Question 4.a above). The hybrid approach for BMR definition is supported by EPA’s Benchmark Dose Technical Guidance (U.S. EPA, 2012) and has most recently been used for modeling birth weight data observed in epidemiologic studies in the PFDA IRIS assessment (U.S. EPA, 2024a). The justification for using the single Kile et al. (2016) study has been strengthened in the assessment. Both the analysis of this single study and the three study meta-analysis are considered for POD derivation for the birth weight endpoint. Ultimately, the POD derived from the Kile et al. (2016) study (0.237 µg/kg-day) was used to derive the osRfD for birth weight (0.079 µg/kg-day), after application of a composite uncertainty factor of three.

[underlined: Public Comment:] One commenter (Students of Johns Hopkins Bloomberg School of Public Health Risk Sciences and Public Policy Institute) objected to the description of the Bangladeshi population of the Kile et al. (2016) study as “US relevant” based on differences in socio-economic factors and that the study itself states that the lower birth weights observed are mediated by gestational age and maternal weight gain throughout pregnancy and thus, the study does not measure the direct effect of iAs on fetal weights. This commenter ultimately recommends that there are other pregnancy outcomes that should be considered for dose-response modeling.

[underlined: EPA Response:] Please see prior EPA responses clarifying that both the single study (Kile et al., 2016) and the three study meta-analysis are now considered for POD derivation for the birth weight endpoint in the revised assessment. Although Kile et al. (2016) was conducted in a Bangladeshi population that differs from the United States with respect to socio-economic factors, the population’s iAs exposures were modest (median: 2.3 µg/kg-day; IQR: 0.9–36 µg/kg-day) compared to higher Bangladeshi populations and thus more in-line with exposures observed in the United States. Regarding whether or not the observed birth weight effects are direct effects of iAs exposure, the study itself notes that it “observed a negative association between prenatal arsenic exposure and birth weight” and that “this toxicological effect was the result of arsenic exposure decreasing gestational age at birth and maternal weight gain during pregnancy.” So, the precursor effect, decreased gestational age, is on the causal pathway between exposure to arsenic and the apical effect of decreased birth weight. Whereas the external peer review draft of the iAs assessment used the beta coefficients for decreased birth weight reported in Table 2 of Kile et al. (2016), it was ultimately considered more appropriate to use the beta coefficients reported in Table 4 in the revised assessment as these beta coefficients empirically measure the indirect effect of iAs on birth weight mediated through gestational age and maternal weight gain. See also SAB Suggestion (1 of 7 Tier 2 for Charge 3.c).

[underlined: Public Comment:] One commenter (Students of Johns Hopkins Bloomberg School of Public Health Risk Sciences and Public Policy Institute) recommended the consideration of studies of iAs-induced teratogenic effects in addition to birth weight.

[underlined: EPA Response:] There were not a sufficient number of studies examining teratogenic outcomes to be included in the evidence synthesis sections for this assessment. Because there was no evidence synthesis section on teratogenic outcomes, the revised assessment retains the decision not to move forward any studies on this topic for dose-response consideration.

## F.7 CHARGE QUESTION 8–UNCERTAINTY FACTORS

8) EPA has evaluated and applied where appropriate uncertainty factors to account for intraspecies variability (UFH), interspecies differences (UFA), database limitations (UFD), duration (UFS), and LOAEL-to-NOAEL extrapolation (UFL) for inorganic Arsenic.
  a) Has uncertainty been adequately accounted for in the derivation of the toxicity values? Please describe and provide suggestions, if needed.
  b) For DCS, diabetes, EPA applied a UFH = 3 to account for potential interindividual differences in toxicokinetics and toxicodynamics related to iAs exposure in humans. EPA determined that a higher UFH is not necessary given that studies that investigated non-cancer effects in sensitive subpopulations were included in the meta-regressions for CVD incidence, IHD incidence, and diabetes. For all three endpoints, the study that had the largest impact on the final pooled slope value was one that investigated effects in a sensitive subpopulation. Please comment on whether this approach is scientifically justified and clearly described.
  c) For pregnancy outcomes, EPA applied a UFH = 3 to account for potential interindividual differences in toxicokinetics and toxicodynamics related to iAs exposure in humans. EPA determined that a higher UFH is not necessary as the Bangladeshi population that formed the basis of the POD for birth weight experiences low birth weight at a much greater rate than U.S populations and represents a sensitive subpopulation. Please comment on whether this approach is scientifically justified and clearly described.

### F.7.1 SAB Peer Reviewer Comments on Cancer Slope Factors (Charge Question 8)

The SAB panel report stated “The only place the UF application is described is in Table 4-18 which makes it difficult to find and evaluate. If the rationale for UF selection is endpoint or study specific, then more text is needed in the RfD derivation section of the document about the basis for UF selection to ensure clarity. The SAB agrees that a UF_A_, UF_S_, or UF_L_ of >1 (i.e., adjustment for animal-to-human, subchronic-to-chronic, or LOAEL-to-NOAEL uncertainties) is not needed. Comments on the rationale for a UF_H_ of 3 for interindividual variability (sensitive subpopulations) are in the response to 8.b below. A UF_D_ for database limitations of 1 (i.e., no adjustment) was used in the draft document. An adjustment for database limitations (i.e., UF_D_ > 1) is made when the available scientific information, or lack thereof, indicates that another effect may occur at lower doses resulting in a lower point of departure (POD) than the critical effect for the RfD (USEPA, 2002 https://www.epa.gov/sites/default/files/2014-12/documents/rfd-final.pdf; USEPA, 2022: Document Display | NEPIS | US EPA (https://ordspub.epa.gov/ords/eims/eimscomm.getfile?p_download_id=545991). It is not known whether neurodevelopmental toxicity is a more sensitive endpoint than the critical effect used for the RfD in the draft document, and this needs to be more fully evaluated. This concern is described in detail under charge question7.a. This additional dose-response evaluation of neurodevelopmental effects recommended in the response to charge question 7.a. will inform the need for application of a UFD > 1.”

The SAB panel further stated “The SAB applauds EPA for the use of dose-response meta-analyses. However, the novel use of sensitivity analyses (i.e., which studies impacted–or not–the analyses) requires more detailed discussion of how this sensitivity/variability is considered in selection of UFH. Stronger scientific support for the choice of UFH would be obtained by considering the full database of studies rather than focusing on a single study. Studies identified through the systematic review process for hazard characterization and dose-response analysis potentially provide insight into human variability and selection of an appropriate value for this UF.”

The panel included as tiered comments several recommendations for EPA to more fully and transparently expand the justifications for the UF_H_ for specific endpoints (see full report for details).

The SAB panel’s tiered comments on Charge Question 8 were:

- 3 Tier 1 Recommended Revision
- 5 Tier 2 Suggested Revisions
- 2 Tier 3 Future Considerations

#### Tier 1 Recommendations for Charge 8

[underlined: SAB Recommendation (1 of 3 Tier 1 for Charge 8):] Additional dose-response assessment evaluation is recommended to assess whether or not neurodevelopmental toxicity is the most sensitive effect.

[underlined: EPA Response:] Developmental neurotoxicity has been modeled and a POD and candidate value is now presented in the revised assessment (see Section 4.5 and 4.6 and Table 4-12). The pooled beta coefficient from the three-study meta-analysis was estimated to be 1.46 IQ points per log_2_(µg/L) maternal urinary tAs concentration (95% CI: −3.03–0.11). Re-expression to the natural scale resulted in a beta coefficient of −0.19 (95%CI: −0.39, 0.01) IQ points per μg/L maternal urinary tAs concentration. A point of departure (POD) for decreased IQ using the re-expressed pooled beta was estimated as 0.315 µg/kg-day using the methods described in Section C.3.1. This POD is used to inform selection of the UF_D_ in the revised assessment (see Section 4.6.3).

[underlined: SAB Recommendation (2 of 3 Tier 1 for Charge 8):] The SAB recommends consideration of whether UF_D_ > 1 is appropriate based on the dose-response evaluation of neurodevelopmental effects.

[underlined: EPA Response:] Developmental neurotoxicity is now modeled in the revised assessment and a candidate value is derived and compared to values for other non-cancer outcomes, ultimately supporting selection of a UF_D_ = 1 in the revised assessment. Specifically, as is reported in the revised assessment, the lowest (most health protective) candidate value (0.06 µg/kg-day, rounded to one significant digit) was derived for diabetes and IHD.

[underlined: SAB Recommendation (3 of 3 Tier 1 for Charge 8):] Remove the justifications in Table 4-18 [of the assessment] for use of a UF_H_ of 3 rather than the default value of 10 that do not appear to be scientifically supportable.

[underlined: EPA Response:] The justification for selection of a UF_H_ = 3 for IHD, diabetes, pregnancy outcomes, developmental neurocognitive effects, and birth weight has been updated in the revised assessment.

Briefly, given that the candidate values for IHD, diabetes, and neurodevelopment are all now based on dose-response meta-analyses incorporating dose-response data from multiple, diverse populations, the justification for these outcomes has been revised to state: A UF_H_ of 3 is applied to account for potential interindividual differences in pharmacokinetics and pharmacodynamics relating to iAs exposure in humans. A higher UF_H_ is not necessary for IHD, diabetes, pregnancy outcomes, or developmental neurocognitive PODs resulting from dose-response meta-analyses. These multi-study meta-analyses investigated a heterogeneous mix of multiple study populations, each of which included and adjusted for many sensitive subpopulations and confounders, including smokers, sex, nutritional status, lifestage, genetic variability, and methylation capacity. Results of the extensive leave-one-out sensitivity analyses showed that when studies are iteratively left out of the Bayesian dose-response meta-analyses of IHD or diabetes, the exclusion of a single study never reduced the estimated pooled logistic slope by more than 63%: excluding the James et al. (2015) IHD study reduces the pooled slope by 61% and excluding the Grau-Perez et al. (2017) diabetes study reduces the pooled slope by 23%. Stated another way, when a single study (possibly reflecting multiple sensitive subpopulations) is included in the dose-response meta-analysis, the pooled slope never increases by more than ~2.5-fold. For example, that is the case when the James et al. (2015) study is included in the dose-response meta-analysis for IHD. The James et al. (2015) study includes multiple potentially sensitive sub-populations, including low-income participants, racial/ethnic groups (i.e., Hispanics), the elderly, those with chronic health conditions (e.g., obesity), etc.). When this study is included in the Bayesian dose-response meta-analysis, the pooled slope increases from 0.0985 to 0.2545, an approximately 2.5-fold increase. This suggests that application of a full 10-fold uncertainty factor to account for interindividual differences is not warranted and a 3-fold UF was applied instead.

Because the single-study analysis of Kile et al. (2016) served as the basis for the candidate value for birth weight, the justification for the selection of 3 for the UF_H_ for this endpoint has been revised to state: “A higher UF_H_ was not deemed necessary for the fetal, newborn, and infant POD derived from the Kile et al. (2016) study because the Bangladeshi population that formed the basis of this birth weight POD is known to have a major public health problem with low birth weight, with a notable difference between its 21% background prevalence and the 8.3% U.S. background prevalence (see discussion in Section 4.4). Further, the effect observed in the Kile et al. (2016) study was much stronger than observed in individual studies included in the three-study meta-analysis, or the pooled estimate of effect derived by that meta-analysis. EPA considers this to support that the Kile et al. (2016) study represents a sensitive subpopulation with respective to susceptibility and that a full UF_H_ = 10 is not warranted for this study. Conversely, even though this study population does represent a sensitivity subpopulation, it is not likely the most sensitive subpopulation and reducing the UF_H_ to 1 is also not warranted.”

#### Tier 2 Suggestions for Charge 8

[underlined: SAB Suggestion (1 of 5 Tier 2 for Charge 8):] The novel use of sensitivity analyses requires more detailed discussion of how sensitivity/variability is considered in selecting the UF_H_.

[underlined: EPA Response:] See EPA response to the 3rd Tier 1 recommendation on charge question 8 above. Briefly, a more thorough discussion of how the sensitivity analyses conducted for IHD and diabetes informed the selection of the UFH has been added to the revised assessment. The results of the leave-one-out sensitivity analyses for IHD and diabetes have been leveraged to support the selection of a UF_H_ = 3 to account for potential interindividual differences in pharmacokinetics and pharmacodynamics relating to iAs exposure in humans. Further, as described above, EPA considers Kile et al. (2016) to present quantitative results for a sensitive subpopulation and that neither a full UF_H_ = 10 or a UF_H_ = 1 is warranted for this study.

[underlined: SAB Suggestion (2 of 5 Tier 2 for Charge 8):] To the extent possible, better utilize the systematic review process and findings to support data-driven selection and application of uncertainty factors.

[underlined: EPA Response:] The IRIS Program’s systematic review process includes tagging studies as “supplemental” during screening (see the iAs protocol and the IRIS Handbook (U.S. EPA, 2022)). Supplemental studies do not meet PECO criteria but could potentially be used to support data-driven approaches for applying uncertainty factors are tracked as supplemental material. However, this process does not guarantee that the data identified are amenable to or sufficient for the development of data-derived uncertainty factors. Even prior to the use of systematic review, the IRIS Program develops data-driven uncertainty factors when possible. For example, pharmacokinetic information has been used for obtaining a data-derived uncertainty factor for intraspecies variability in the 2011 IRIS Toxicological Review of Dichloromethane.

[underlined: SAB Suggestion (3 of 5 Tier 2 for Charge 8):] Citations for key studies and the basis for important conclusions (such as the basis for water consumption of 0.017 L/kg-day and studies of CVD and diabetes referred to in the sensitivity analyses) should be provided throughout the document.

[underlined: EPA Response:] Citations for key studies used to justify the selection of the UF_H_ for meta-analysis outcomes have been added to Table 4-13 and discussions therein, if necessary. Specifically, regarding the 0.017 L/kg-day water consumption rate cited as the rationale for identifying a study population as a “sensitive subpopulation with respect to degree of exposure,” the SAB panel noted this was not an appropriate rationale for reducing the UF_H_ and thus has been removed from the rationale in the revised draft.

[underlined: SAB Suggestion (4 of 5 Tier 2 for Charge 8):] For IHD incidence, the SAB recommends providing a different rationale for reducing the UF_H_ from the default value of 10 because a more highly exposed population by virtue of a greater water intake is not a sensitive population.

[underlined: EPA Response:] See EPA response to the 3rd Tier 1 recommendation on Charge Question 8 above. Briefly, the justification for reducing the UF_H_ for Bayesian dose-response meta-analysis outcomes (IHD and diabetes) has been simplified to state that the meta-analyses were conducted in a heterogenous mix of multiple study populations, each of which included and adjusted for many sensitive subpopulations. Specific information for each individual outcome, with necessary citations, has been added to the justification text.

[underlined: SAB Suggestion (5 of 5 Tier 2 for Charge 8):] It is recommended that EPA further substantiate the selected UF_H_ for the pregnancy outcome–and specifically provide rationale for departing from the default value of 10–using data from the evidence base reviewed, as well as clarifying the existing rationale around sensitivity of the Bangladeshi population to the effects of iAs (vs. other factors) and of the specific study selected from the 102 screened studies.

[underlined: EPA Response:] See EPA response to the 4th Tier 1 recommendation on Charge Question 8 and 7th Tier 1 recommendation for Charge Question 7 above. Briefly, the rationale for applying a UF_H_ = 3 to the multi-study meta-analysis uses the same rational as the Bayesian dose-response meta-analysis endpoints; the assessment has been revised accordingly.

For the single-study POD based on the Kile et al. (2016) study, the justification for the UF_H_ has been revised to state: “A higher UF_H_ was not deemed necessary for the fetal, newborn, and infant POD derived from the Kile et al. (2016) study because the Bangladeshi population that formed the basis of this birth weight POD is known to have a major public health problem with low birth weight, with a notable difference between its 21% background prevalence and the 8.3% U.S. background prevalence (see discussion in Section 4.4). Further, the effect observed in the Kile et al. (2016) study was much stronger than observed in individual studies included in the three-study meta-analysis, or the pooled estimate of effect derived by that meta-analysis. EPA considers this to be support that the Kile et al. (2016) study represents a sensitive subpopulation with respective to susceptibility and that a full UF_H_ = 10 is not warranted for this study. Conversely, even though this study population does represent a sensitivity subpopulation, it is not likely the most sensitive subpopulation and reducing the UF_H_ to 1 is also not warranted.”

#### Tier 3 Future Consideration Charge 8

[underlined: SAB Future Consideration (1 of 2 Tier 3 for Charge 8):] Better utilize the systematic review process and findings to support data-driven selection and application of uncertainty factors.

[underlined: EPA Response:] Please see EPA’s response to SAB’s suggestion (2 of 5 Tier 2 for Charge Question 8) above.

[underlined: SAB Future Consideration (2 of 2 Tier 3 for Charge 8):] Because guidance around UFs was generally drafted prior to the use of observational data in developing toxicity reference values, it would be helpful for the Agency to consider refining the recommendations for choice of UFs to be more aligned with describing and characterizing uncertainties in the use of observational data, including guidance for determining when populations are considered sensitive and/or representative of toxicokinetic and toxicodynamic variability.

[underlined: EPA Response:] EPA appreciates this consideration for potential use in future efforts to refine EPA guidelines on application of uncertainty factors in EPA assessments.

### F.7.2 Public Comments on Uncertainty Factors (Charge Question 8)

[underlined: Public Comment:] Two commenters (Exponent; Pesticide Policy Coalition) provided comments on the representativeness of studies included in the dose-response analyses. The first commenter (Exponent) noted that most of the epidemiologic data is derived from relatively low-resource populations where iAs doses may be underestimated by exposure assessments that cannot adequately account for lifestyle factors and therefore preclude reliable extrapolation to US populations. This commenter further suggests that many of these populations have greater susceptibility to arsenic toxicity due to nutritional deficiencies such as folate and therefore represent populations that are more sensitive than the general US population. This commenter ultimately recommends that 95th percentile upper bound estimates or large uncertainty factors for individual susceptibility are less warranted for the iAs assessment. The second commenter (Pesticide Policy Coalition) concurred, stating that while it is important to study vulnerable sub-populations, the iAs assessment over relies on studies with populations that are not representative of the US population and recommends that the assessment better account for risks to the US general population.

[underlined: EPA Response:] EPA disagrees that the epidemiologic data used in modeling is derived mostly from low-resource populations that are not representative of U.S. populations (see also previous responses to comments provided under Charge Question 4 on this same topic). The endpoint-specific study selection tables (see Tables C-22, C-33, C-42, C-50, C-63, and C-64) demonstrate that many U.S. population studies are included in EPA’s analyses along with studies conducted in geographic locations that are reasonably expected to be representative of U.S. populations (i.e., Europe, Mexico, etc.). Some low-resource populations did pass the dose-response study selection process and are included in the meta-analyses (i.e., Bangladesh, Inner Mongolia, etc.), which enhances the ability of the analyses to capture interindividual variation. Conducting meta-analyses across multiple, diverse populations should be seen as a strength of the analysis in that it allows for the inclusion of multiple populations inclusive of many different potentially susceptible sub-groups. In fact, this rationale serves as the primary basis for EPA’s selection of a reduced UF_H_ = 3, rather than the default UF_H_ = 10.

Further, inclusion of studies of sensitive subpopulations and dose-response modeling of data from these sensitive subpopulations is consistent with EPA guidelines (U.S. EPA, 2002b, 2022). Indeed, the definition of the reference dose is “an estimate (with uncertainty spanning perhaps an order of magnitude) of a daily oral exposure for a chronic duration (up to a lifetime) to the human population (including sensitive subgroups) [emphasis added] that is likely to be without an appreciable risk of deleterious effects during a lifetime.” Therefore, the inclusion of studies of sensitive subpopulations is both consistent with EPA guidelines and the definition of the reference dose.

[underlined: Public Comment:] One commenter (Students of Johns Hopkins Bloomberg School of Public Health Risk Sciences and Public Policy Institute) provided multiple comments stating that uncertainty has not been adequately accounted for in the assessment and recommended that the interindividual variability uncertainty factor be increased to a value of 10 for all endpoints. Regarding cardiovascular diseases, this commenter provided a list of populations that are susceptible to development of cardiovascular diseases, including the elderly, youth, economically disadvantaged, racial and ethnic minorities, the uninsured, low-income children, and individuals with chronic health conditions. This commenter also noted the specific characteristics the EPA identifies as contributing to higher rates of CVD and faulted the studies EPA used for CVD modeled for not including these populations. This commenter also recommended that the UFH for diabetes be increased from 3 to 10 to account for sensitive subpopulations that are more susceptible to damage from arsenic exposure and from complications of diabetes. One commenter criticized the selection of a UFH for pregnancy outcomes as not scientifically justified given the Kile et al. (2016) study was not ethnically diverse, did not account for high-risk pregnancies, and indirect factors such as nausea could be more susceptible to interindividual differences. This commenter recommended that the UFH for pregnancy outcomes be increased to 10.

[underlined: EPA Response:] Application of a UF_H_ of 3 (instead of a UF_H_ of 1) acknowledges that certain known susceptible groups or potentially more sensitive subpopulations are not included in the studies used to conduct dose-response meta-analyses and that studies consisting of only the most sensitive subpopulation are not included in the dose-response meta-analysis. However, some sensitive subpopulations are included in each of the analyses, which warrants decreasing the UF_H_ from the default of 10. For example, consider the James et al. (2015) study included in the IHD analysis and identified as the most impactful study in terms of influence on estimation of the pooled slope value (see EPA response to SAB Recommendation (3 of 3 Tier 1 for Charge 8) above). The study population for this study includes many participants that belong to groups the commenter identifies as susceptible to the development of cardiovascular diseases. Notably, this study includes participants with chronic health conditions (e.g., obesity), the elderly (participant ages up to 64 years), racial/ethnic minorities, and participants with low income. Other studies included in the dose-response meta-analyses also include diverse study populations. The justification for the UF_H_ for all outcomes has been revised in the final assessment (see Section 4.6.3). Please see prior EPA responses to SAB comments on this topic above, including for the Kile et al. study specifically.

[underlined: Public Comment:] Two commenters (Exponent; European Arsenic Consortium) provided comments stating that the interindividual variability uncertainty factor was too large. The first commenter (Exponent) noted that the RfD in the external peer review draft of the assessment was estimated using the same value for the interindividual variability uncertainty factor (UFH = 3) as the 1991 RfD. This commenter suggested that given the 1991 value was based on a single study and that the current assessment should have more confidence in estimating the point of departure since it is based on consideration of more human studies, including human studies of populations that are more susceptible to cardiovascular disease than the general US population. This commenter further suggested that basing the RfD on a BMDL05 is more conservative than using a NOAEL (as was done in the 1991 assessment), and thus a UFH is unnecessary. The second commenter (European Arsenic Consortium) provided a similar recommendation that since the iAs assessment considers several human studies, the current UFH is overly conservative.

[underlined: EPA Response:] As stated above, the candidate values for IHD, diabetes, birth weight, and neurodevelopment are all now based on dose-response meta-analyses incorporating dose-response data from multiple, diverse study populations that incorporate sensitive subpopulations. Given the use of multi-study meta-analyses to derive the candidate values, it was determined that decreasing the UFH from the default 10 to 3 was warranted. However, it is not reasonably assumed that the studies used in the meta-analyses include all (or most) of the known susceptible groups or potentially more sensitive subpopulations and thus it is not appropriate to decrease the UFH to a value of 1. Regarding whether a UFH is needed when using a BMDL05 as the basis for the point of departure, it is not always the case that a BMDL05 will always be more conservative than a NOAEL.

[underlined: Public Comment:] One commenter (Students of Johns Hopkins Bloomberg School of Public Health Risk Sciences and Public Policy Institute) recommended that a dose-response meta-analysis approach similar to what was done for CVD and diabetes be considered for pregnancy outcomes.

[underlined: EPA Response:] In the revised assessment, studies of pregnancy outcomes (i.e., birth weight) that used maternal urinary tAs as the dose metric are now considered for inclusion in dose-response analyses, which ultimately permitted conducting a meta-analysis (see the response to the 4th Tier 1 recommendation for Charge Question 7). A point of departure for decreased birthweight of 1.4 µg/kg-day is now derived in the revised assessment, using the pooled beta as described in Section C.2.

## F.8 CHARGE QUESTION 9–RFD

9) From the identified human health effects of iAS and the derived organ-specific toxicity values for diabetes, DCS effects and pregnancy outcomes, an RfD of 0.031 μg/kg-day based on increased CVD incidence in humans was selected. This RfD is expected to be protective against all noncancer adverse health effects associated with iAs and across all lifestages. Please comment on whether the selected RfD is scientifically justified and clearly described.

### F.8.1 SAB Peer Reviewer Comments on the RfD (Charge Question 9)

The SAB panel report stated “Regarding scientific justification of the proposed RfD, the overall RfD based on increased CVD incidence should be reconsidered for several reasons, which fall into two general categories discussed separately below. First, it is unclear that an RfD developed using traditional methods (i.e., estimation of a POD and application of uncertainty factors) is scientifically supportable and health protective for non-cancer effects with the dose-response relationship identified in the draft document. Additionally, it is unclear whether the health endpoint, point of departure, and uncertainty factors selected for development of the RfD are scientifically supportable and sufficiently health protective.”

The SAB panel report then sub-divided additional comments, as summarized below on specific aspects of the RfD derivation:

- Is development of an RfD for inorganic arsenic scientifically supportable: “The inability to identify a threshold for DCS (IHD and CVD) and diabetes caused by iAs exposure suggests that development of an RfD for iAs may not be appropriate, like the conclusion mentioned above for lead.”
- Is the proposed RfD based upon an appropriate health endpoint, point of departure, and uncertainty factors:
  ○ Consideration of neurodevelopmental effects in RfD development: As noted in the response to charge question 7, it may be feasible to perform dose-response for neurodevelopmental effects to determine whether it is a more sensitive endpoint that is sufficiently strongly supported to be considered as the basis of the overall RfD.”
  ○ Consideration of IHD rather than CVD in RfD development: “The responses to charge question 4a and 7b provide a strong recommendation that RfD development for DCS focus on IHD rather than CVD. As noted in the responses to the other charge questions, IHD represents a more homogeneous disease process and endpoint in contrast to the diversity of effects included in CVD. Thus, IHD, rather than CVD, is the preferred endpoint for evaluating DCS.”
  ○ Consideration of mortality as well as incidence in RfD development: “EPA should consider the strengths and limitations of the database supporting dose-response meta-analysis to determine whether incidence or mortality is more appropriate as the basis for the POD and RfD.”
  ○ Choice of BMR for RfD development: “The draft IRIS document (p. 4-59–4-60) states that a BMDL05 was used instead of a BMDL01 because CVD, IHD, and diabetes are not “frank effects and do not support a lower BMR on the basis of severity” and that, for this reason, the fact that “BMD01 estimates are well below the low end of observable dose range, whereas BMD05 estimates are well within, but still close to the low end of the observable range” becomes more important in selecting the BMR. However, as discussed in the response to charge question 7, the SAB does not agree that these are not frank effects and concludes that the choice of the BMDL05 rather than the BMDL01 should be reconsidered in light of the severity of these effects and the disease burden that it represents in the U.S. population.”
  ○ Discussion of uncertainty: “Additional discussion of the qualitative and quantitative uncertainties associated with the RfD is needed (in addition to the characterization of confidence that is already included), consistent both with standard practice in risk assessment and the IRIS handbook (USEPA, 2022).”

The SAB panel’s tiered comments on Charge Question 9 were:

- 5 Tier 1 Recommended Revision
- 2 Tier 2 Suggested Revisions
- 0 Tier 3 Future Considerations

#### Tier 1 Recommendations for Charge 9

[underlined: SAB Recommendation (1 of 5 Tier 1 for Charge 9):] The IRIS document should clearly present the issues relevant to the assessment of risks of non-cancer effects, including examples of calculations of risk levels for non-cancer endpoints at various iAs doses.

[underlined: EPA Response:] The revised assessment includes extensive results of the probabilistic Bayesian dose-response analyses for non-cancer outcomes, including thorough discussions of the methods, presentation of lifetime extra risks for non-cancer outcomes across a wide range of possible iAs exposure levels, and characterization of uncertainties in the analysis relating to modeling inputs, parameterization of the Bayesian models, and the set of studies used in the dose-response meta-analysis. As part of the documentation of non-cancer modeling results and toxicity value derivations, lifetime extra risks over a range of low- to moderate exposures are presented in the assessment (see Tables 4-3, 4-5, 4-7, and 4-9).

[underlined: SAB Recommendation (2 of 5 Tier 1 for Charge 9):] Risk levels for non-cancer and cancer effects at the same dose of iAs should be presented and compared, with recognition that both types of health effects from low-dose exposure to iAs are of concern.

[underlined: EPA Response:] The external peer review draft of the assessment presented lifetime extra risk values across a range of possible iAs exposures for cancer and non-cancer outcomes individually. In the revised assessment, the presentation of individual outcome risk values is retained in their respective dose-response sub-sections, but a new table (Table 4-10) in Section 4.3.10 has been added to the assessment that collates risk values for all outcomes to ease comparison across outcomes.

[underlined: SAB Recommendation (3 of 5 Tier 1 for Charge 9):] EPA should reconsider whether setting an RfD for iAs is scientifically supportable, and detailed discussion of this issue should be presented in the IRIS document. This discussion should address the following issues:

- Whether an RfD is appropriate for a contaminant with non-cancer effects that exhibit a low-dose linear (non-threshold) dose-response
- The need for a science-policy decision on a risk level that does not represent appreciable risk is an RfD for iAs is developed.
- Consideration of an alternative approach for assessment of non-cancer effects of iAs based on the polynomial equations or a slope factor that relates the risk and dose, with recognition of the need to select a target risk level for non-cancer effects if this approach is used.

[underlined: EPA Response:] The IRIS assessment for iAs has taken a holistic approach to presenting toxicity values for both cancer and non-cancer outcomes in order to meet the varied needs of our Agency and external stakeholders. The assessment includes the derivation of a deterministic “traditional” RfD (along with organ- or system-specific RfDs, osRfDs) for the non-cancer endpoints via the application of uncertainty factors to a single point-of-departure identified from the underlying probabilistic dose-response analysis. Presenting a deterministic RfD is considered essential because certain statutory decisions made by EPA Regional and Program Offices rely on the use of such a value. Currently, EPA does not have human health risk assessment guidelines for application of probabilistic methods to non-cancer outcomes. This situation, providing both probabilistic and deterministic toxicity values for the same non-cancer endpoint in an assessment, is the natural progression in how EPA derives and presents toxicity values as it explores the development and application of probabilistic approaches while still providing traditional (i.e., deterministic) toxicity values that are required by some stakeholders. Probabilistic risk-at-a-dose values are presented for both cancer and non-cancer outcomes in an effort to demonstrate how modeling and risk estimation derivation approaches can be harmonized between the two types of effects, a recommendation that has long been made with respect to Agency documents.

The iAs assessment provides multiple toxicity values for both cancer and non-cancer endpoints in order to meet a broad range of stakeholder needs. For non-cancer endpoints, the assessment includes the standard derivation of a reference dose (RfD) along with organ- or system-specific RfDs (osRfDs) via the application of uncertainty factors to points-of-departure (PODs). The PODs supporting the RfD are based on the lower confidence limit of the benchmark dose (BMDL) identified from the underlying Bayesian dose-response analyses for ischemic heart disease (IHD) and diabetes (see Section 4.6). Certain decisions made by EPA Regional and Program Offices rely on the use of RfDs to meet their statutory requirements. Likewise, cancer slope factors are estimated for individual cancer endpoints and a combined cancer oral slope factor (OSF) is estimated based on bladder and lung cancers (see Section 4.7). The iAs assessment also includes extensive results of the probabilistic Bayesian dose-response analyses for cancer and non-cancer outcomes, where “risk-at-a-dose” values are presented across a range of low- to moderate iAs exposure scenarios.

Presentation of traditional, non-cancer toxicity values (i.e., the RfD and osRfDs) as well as probabilistic toxicity values (i.e., risk-at-a-dose values) will allow users of the iAs assessment to estimate lifetime extra risk for individual endpoints at levels above, or below, the final RfD, noting that the definition of the RfD is “an estimate (with uncertainty spanning perhaps an order of magnitude) of a daily oral exposure to the human population (including sensitive subgroups) that is likely to be without an appreciable risk of deleterious effects during a lifetime.” Both the deterministic and probabilistic toxicity values are useful within specific decision contexts. However, they involve different assumptions, methods, and uncertainties in their derivation. These differences would be considered, dependent on context, during development of subsequent risk assessments by EPA or others.

[underlined: SAB Recommendation (4 of 5 Tier 1 for Charge 9):] Among the other outcomes discussed in the previous sections, use of neurodevelopmental effects in RfD development should be reconsidered. The feasibility of performing dose-response evaluation and identifying a POD for neurodevelopmental effects should be evaluated. If it is determined that it is not feasible to develop a POD for neurodevelopmental effects, application of a database UF >1 to account for potentially more sensitive neurodevelopmental effects should be considered.

[underlined: EPA Response:] The dose response approach for neurodevelopmental outcomes has been revised. See responses to SAB comments for charge questions 3.d and 7 (specifically see response to the 1st and 3rd Tier 1 recommendations under Charge Question 7).

[underlined: SAB Recommendation (5 of 5 Tier 1 for Charge 9):] Consistent with the IRIS Handbook, an uncertainty section should be added to the document summarizing uncertainties in the non-cancer assessment and resulting reference values.

[underlined: EPA Response:] Uncertainties in the analysis are discussed for meta-analysis outcomes in their respective sub-sections in the dose-response section. Uncertainties in the dose-response analysis have been summarized in Section 4.3.9 of the revised assessment and in Section 4.6.4 where the overall confidence in the candidate values is discussed. Briefly, uncertainties in the studies used in the dose-response analysis, the quantification of candidate values, and confidence in the evidence base supporting the modeled endpoint are all considered in the overall characterization of confidence for the organ-specific candidate values.

#### Tier 2 Suggestions for Charge 9

[underlined: SAB Suggestion (1 of 2 Tier 2 for Charge 9):] The discussion of how background exposure was considered in the analyses presented in the draft document should be expanded, including a clear presentation of the information needed for application of the assessment’s conclusions.

[underlined: EPA Response:] A fuller discussion of how the assumed U.S. background iAs exposure level (consisting of dietary and drinking water components) has been added to the revised assessment in multiple sections and tables.

[underlined: SAB Suggestion (2 of 2 Tier 2 for Charge 9):] The following additional recommendations also apply if a decision is made to develop an RfD for arsenic:

(1) The section on RfD derivation in the main document should clearly present all information needed to understand the methodology used to develop the RfD.
(2) The predicted risk at the RfD should be presented for each non-cancer effect for which no threshold is identified, and it should be indicated that this risk level is not considered to represent an appreciable risk.
(3) EPA should evaluate whether fatal occurrences of IHD and/or incidence of IHD (including both fatal and non-fatal occurrences) is most appropriate for the basis of the RfD. The document should include a discussion of qualitative and quantitative uncertainties associated with the RfD including how uncertainties related to factors such as systemic bias, residual bias, and uncontrolled confounding were considered for each outcome.

[underlined: EPA Response:] The rationale for presenting osRfDs and an RfD is provided in response to the Tier 1 recommendation above. The bulleted suggestions (numbered by EPA) in the Tier 2 comment above overlap with other SAB comments. The cross-referencing to EPA’s responses on these bulleted comments is summarized below.

(4) See SAB Recommendation 3 of 6 Tier 1 for Charge 4.b, SAB Recommendation 1 of 8 and 5 of 9 Tier 1 for Charge 7, and SAB Suggested Revision 10 of 16 and 11 of 16 Tier 2 for Charge 7.
(5) See SAB Recommendation 2 of 2 Tier 1 for Charge 9.
(6) See SAB Suggestion 3 of 3 Tier 2 for Charge 6 and SAB Recommendation 6 of 9 Tier 1 for Charge 7.

#### Tier 3 Future Consideration Charge 9

The reviewers had no Tier 3 future considerations.

### F.8.2 Public Comments on the RfD (Charge Question 9)

[underlined: Public Comment:] One commenter (University of California, San Francisco Program on Reproductive Health and the Environment) recommended that EPA follow NASEM guidance to specify a risk-specific dose in place of a traditional RfD.

[underlined: EPA Response:] The revised assessment has included risk-specific doses for outcomes modeled with the Bayesian dose-response meta-analysis plus lifetable approach. This means for bladder cancer, lung cancer, IHD, and diabetes the assessment provides dose-specific risks. For non-cancer outcomes, both deterministic “traditional” and probabilistic toxicity values are retained in the assessment to meet the varied needs within EPA and for potentially varied uses by external stakeholders.

[underlined: Public Comment:] One commenter (Dean Casey) requested that the RfD and CSF values be presented in units of mg/kg-day in addition to µg/kg-day to maintain continuity with previous assessments and to clearly show the effect of the new toxicity values compared to previous values.

[underlined: EPA Response:] This has been done in the revised assessment.

43 Charge questions, as submitted to the SAB for the external peer review, are recapitulated verbatim in italics under each sub-heading.

44 During the revisions process, one domain rating changed for James et al. (2015), but the overall confidence remained the same (see HAWC).