# APPENDIX D INFORMATION IN SUPPORT OF HAZARD IDENTIFICATION AND DOSE-RESPONSE ANALYSIS

## D.1 TOXICOKINETICS

### D.1.1 Absorption

Water-soluble forms of inorganic arsenic (both trivalent and pentavalent) are readily absorbed from the GI tract in experimental animal models [about 80%–90% 0.62 mg/kg of sodium arsenate (Freeman et al., 1995)] as well as humans [Pomroy et al. (1980), who recovered 62% of a 0.06 ng dose of arsenic in seven days]. Monomethyl arsonic acid (MMA^V^) and dimethylarsinic acid (DMA^V^) also appear to be well absorbed (75%–85%) in humans and experimental animals (Yamauchi and Yamamura, 1984; Stevens et al., 1977; Hughes et al., 2005; Buchet et al., 1981). Using an in vivo swine test, however, Juhasz et al. (2006) determined that MMA (oxidation state not specified) and DMA (oxidation state not specified) were poorly absorbed, with only 16.7% and 33.3%, respectively, bioavailable.

Laparra et al. (2006) used a Caco-2 permeability model, which measured transport through a monolayer of human intestinal cells, to examine the intestinal permeability of As^III^. A decrease in the apical to basolateral permeability with increasing dose was found, indicating the presence of a saturable intestinal transport system. The data also indicated that Caco-2 cells have a secretory system for As^III^. In an earlier study, Laparra et al. (2005b) demonstrated that the retention and transport of As^III^ in Caco-2 cells was more efficient than that of As^V^. However, this could have been due to the presence of phosphate in the culture medium, which would compete with arsenate for transport across the membrane.

Gastrointestinal absorption of low-solubility arsenic compounds such as arsenic trisulfide, lead arsenate, arsenic selenide, gallium arsenide (Yamauchi et al., 1986; Webb et al., 1984; Mappes, 1977), and arsenic-contaminated soil (Freeman et al., 1995) is much less efficient than that of soluble inorganic arsenic compounds. The degree of absorption of arsenic from soil was found to be dependent on the arsenic species present in the soil and on the type of soil. Juhasz et al. (2007) performed in vivo bioavailability studies in swine and determined that the bioavailability of total arsenic in soils was highly variable, with a range of 6.9% to 74.7% depending on the soil type. They also determined that a simplified bioaccessibility extraction test (SBET; a rapid in vitro chemical extraction method) had results highly correlated with the in vivo results. Therefore, they concluded that the less expensive in vitro test was just as effective for determining bioavailability.

There is little information concerning the bioavailability of inorganic arsenic from various types of food (NRC, 1999, 2001). However, there have been studies examining the bioaccessibility of arsenic from rice (Laparra et al., 2005a; Juhasz et al., 2006). Laparra et al. (2005a) determined that while cooking rice (they tested several types but did not specify them) in deionized water caused no change in arsenic content compared to the raw form, cooking in water contaminated with 0.5 μg/mL of As^V^ increased the inorganic arsenic content 5- to 17-fold over the raw rice. Laparra et al. (2005a) subjected the rice samples (10 grams) to an in vitro simulated digestion process. They measured levels of soluble arsenic to determine bioaccessibility. The results demonstrated that large amounts of the arsenic (i.e., 63%–99%), mainly in the pentavalent form, were bioaccessible for intestinal absorption. Ackerman et al. (2005) also found 89%–105% bioaccessible arsenic in different samples of white and brown rice cooked in water containing As^V^.

Juhasz et al. (2006) examined the bioavailability of arsenic from rice (mainly white rice samples) using an in vivo swine assay. Quest rice was grown in arsenic-contaminated water and cooked in arsenic-free water. This caused the rice to contain arsenic, mainly in the form of DMA. Administration of the cooked rice to swine demonstrated a bioavailability similar to that observed after a single oral administration of DMA in water (i.e., 33.3%). Basmati white rice cooked in water contaminated with 1,000 ppb of As^V^, which contained entirely inorganic arsenic as a result of the arsenate in the cooking water, had a bioavailability of 89.4%.

Although there have been no studies performed on the rate of inorganic arsenic absorption through intact human skin, systemic toxicity due to high dermal occupational exposure to aqueous inorganic arsenic solutions indicates that the skin may be a significant exposure route (Hostýnek et al., 1993). The systemic absorption via the skin from less concentrated solutions, however, appears to be low (NRC, 1999). An in vivo study by Wester et al. (1993) demonstrated that 2% to 6% of radiolabeled arsenate (as a water solution) was absorbed by rhesus monkey skin over a 24-hour period. Results demonstrated that the lower dose (0.000024 μg/cm^2^) was absorbed at a greater rate (6%) than the higher arsenic exposure (2.1 μg/cm^2^; 2%), but the difference did not reach statistical significance. Wester et al. (2004) performed another in vivo dermal absorption study using female rhesus monkeys. Using the levels excreted in the urine and the applied dose, they calculated that 0.6% to 4.4% was absorbed in the three monkeys tested, which was similar to their previous results. In vitro results on human skin (from donors) demonstrated a 24-hour absorption of 1.9% (Wester et al., 1993). Mouse dorsal skin was demonstrated to absorb 30% to 60% of applied arsenic (Rahman et al., 1994) using similar in vitro testing, with 60% to 90% of the absorbed arsenic being retained in the skin. NRC (1999) suggests this indicates that inorganic arsenic binds significantly to skin and hair. Lowney et al. (2007) found that dermal absorption of arsenic from soils was negligible in an in vivo study in rhesus monkeys.

Harrington et al. (1978) compared arsenic metabolite levels in the urine from a group of people in Fairbanks, Alaska, who had arsenic-contaminated water (345 ppb) in their home, but drank only bottled water, with the levels measured in a group of people who drank home water containing less than 50 ppb. The results demonstrated that the group with high arsenic in their water had close to the same average concentration of total arsenic metabolites in their urine (i.e., 43 μg/L) as the group who drank home water with less than 50 ppb arsenic (i.e., 38 μg/L in urine), indicating possible dermal absorption via bathing or other exposure sources. Levels of arsenic in the bottled water, however, were not measured. Possible exposure through using contaminated water for cooking also was not examined.

### D.1.2 Distribution

The retention and distribution patterns of arsenic species are strongly dependent on their chemical properties. While both As^III^ and As^V^ bind to sulfhydryl groups, As^III^ has approximately a 5- to 10-fold greater affinity for sulfhydryl groups than As^V^ (Jacobson-Kram and Montalbano, 1985). Cellular uptake rates and resulting tissue concentrations are substantially lower for the pentavalent than for the trivalent forms of arsenic. DMA (an important metabolite of inorganic arsenic) appears to be more readily excreted than MMA (NRC, 2001). Liu et al. (2002) found arsenite to be transported into cells by aquaglycoporins (AQP7 and AQP9), whose usual substrates are water and glycerol. Liu et al. (2006b) also detected transport of monomethylarsonous acid (MMA^III^) by AQP9. MMA^III^ was transported at a rate nearly 3 times faster than As^III^. A hydrophobic residue at position 64 was required for the transport of both species, suggesting that both species are transported by AQP9 using the same translocation pathway. As^V^, however, has been suggested to be transported by the phosphate transporter (Huang and Lee, 1996). Retention of arsenic can vary not only with its form, but also with tissue (Thomas et al., 2001). Other factors that affect the retention and distribution of arsenic include the chemical species, dose level, methylation capacity, valence state, and route of administration.

### D.1.3 Transport in Blood

Once arsenic is absorbed, it is transported in the blood throughout the body. In the blood, inorganic arsenic species are generally bound to sulfhydryl groups of proteins and low-molecular-weight compounds such as glutathione (GSH) and cysteine (NRC, 1999). Binding of As^III^ to GSH has been demonstrated by several investigators (Scott et al., 1993; Delnomdedieu et al., 1994a; Delnomdedieu et al., 1994b; Anundi et al., 1982). Because of the different binding and transport characteristics of various arsenic compounds, the persistence in the blood varies across species. Inorganic arsenic elimination in humans has been observed to be triphasic, with first-order half-lives for elimination of 1 hour, 30 hours, and 200 hours: Mealey et al. (1959) used AsIII, Pomroy et al. (1980) used AsV. A single intravenous (iv) dose of 5.8 μg As/kg body weight (in the form of 73As^V^) administered to two male chimpanzees had a half-life plasma elimination rate of 1.2 hours and a half-life elimination rate from red blood cells (RBCs) of about 5 hours (Vahter et al., 1995b).

Rats retain arsenic in the blood considerably longer than other species because dimethylarsenous acid (DMA^III^) and DMA^V^ accumulate in RBCs, apparently bound to hemoglobin (Vahter, 1983; Vahter et al., 1984; Odanaka et al., 1980; Lerman and Clarkson, 1983). Naranmandura et al. (2007) found that 75% of an oral dose of arsenite accumulated in rat RBCs mainly in the form of DMA^III^; however, less than 0.8% of the same dose to hamsters was found in their RBCs. Rats maintained this level in their RBCs for at least 7 days whereas the treated hamsters had levels equivalent to those in controls by 3 days after the administered dose. Stevens et al. (1977) calculated an elimination half-life for inorganic arsenic of 90 days in rat whole blood after a single oral dose of 200 mg/kg. Lanz et al. (1950) also reported a high retention of arsenic in the blood of cats, although less than in the rat. However, they did not determine if the retained arsenic was in the form of DMA.

The relative concentration of arsenic in human plasma and RBCs apparently differs depending on exposure levels and the health status of the exposed individuals. Heydorn (1970) reported that healthy people in Denmark with low arsenic exposures had similar arsenic concentrations in their plasma and RBCs (2.4 μg/L and 2.7 μg/L, respectively; the RBC:plasma ratio was 1.1). However, normal healthy Taiwanese exposed to arsenic-contaminated water had plasma levels of 15.4 μg/L and RBCs levels of 32.7 μg/L (RBC:plasma ratio 2.1). Blackfoot disease (BFD) patients and their unaffected family members had 38.1 μg/L and 93 μg/L of arsenic species in their plasma and RBCs, respectively (RBC:plasma ratio 2.4). These results indicate a different distribution between the RBCs and the plasma depending on exposure levels. However, examining the BFD patients and their families, who presumably have the same exposure levels, demonstrates a different distribution, possibly due to disease state. BFD patients had a ratio of 3.3 (106 μg/L in RBCs and 32.3 μg/L in plasma) compared to 1.8 (81 μg/L in RBCs and 45.2 μg/L in plasma) in family members without BFD. This indicates that accumulation of arsenic in the RBCs is greater as exposure increases and possibly even greater when health is compromised. The ratio between plasma and RBC arsenic concentrations may also depend on the exposure form of arsenic (NRC, 1999).

### D.1.4 Tissue Distribution

Once arsenic compounds enter the blood, they are transported and taken up by other tissues and organs, with a large proportion of ingested material being subject to “first pass” processing through the liver. Uptake varies with arsenic species, dose, and organ. The observed uptake of inorganic arsenic (mainly As^III^) in the skin, hair, oral mucosa, and esophagus is most likely due to the binding of inorganic arsenic species with sulfhydryl groups of keratins in these organs. In studies using rabbits and mice, where the transfer of methyl groups from Sadenosylmethionine- (SAM; a proposed major reaction during arsenic metabolism; see Section 3.3) was chemically inhibited, the concentration of arsenic in most tissues (especially the skin) was found to be increased (Marafante and Vahter, 1984). The important role of chemical binding of arsenic species also is supported by the observed tissue distribution in the marmoset monkey, which does not methylate inorganic arsenic (Vahter et al., 1982).

Human subjects also have demonstrated high concentrations of arsenic in tissues containing a high content of cysteine-containing proteins, including the hair, nails, skin, and lungs. Total arsenic concentrations in these tissues of human subjects exposed to background levels of arsenic ranged from 0.01 to 1.0 mg/kg of dry weight (Liebscher and Smith, 1968; Cross et al., 1979). Benign and malignant skin lesions from 14 patients, with a minimum of 4 years of exposure to inorganic arsenical medication, had higher arsenic levels (0.8 to 8.9 ppm) than six subjects with no history of arsenic intake (0.4 to 1.0 ppm) (Scott, 1958). In West Bengal, India, where the average arsenic concentration in the drinking water ranges from 193 to 737 ppb, arsenic concentrations in the skin, hair, and nails were 1.6–5.5, 3.6–9.6, and 6.1–22.9 mg/kg dry weight, respectively (Das et al., 1995). Mandal et al. (2004) measured different arsenic species in the hair and fingernails of 41 subjects in West Bengal, India, who were drinking arsenic-contaminated water and in blood from 25 individuals who had stopped drinking contaminated water 2 years earlier. Results were fingernail contained As^III^ (62.4%), As^V^ (20.2%), MMA^V^ (5.7%), DMA^III^ (8.9%), and DMA^V^ (2.8%); hair contained As^III^ (58.9%), As^V^ (34.8%), MMA^V^ (2.9%), and DMA^V^ (3.4%); RBCs contained arsenobetaine (22.5%) and DMA^V^ (77.5%); and blood plasma contained arsenobetaine (16.7%), As^III^ (21.1%), MMA^V^ (27.1%), and DMA^V^ (35.1). However, the amount of arsenic in these tissues resulting from other exposure pathways (e.g., dermal exposure) was not determined.

The longest retention of inorganic arsenic in mammalian tissues during experimental studies has been observed in the skin (Marafante and Vahter, 1984), hair, squamous epithelium of the upper GI tract (oral cavity, tongue, esophagus, and stomach wall), epididymis, thyroid, skeleton, and the lens of the eye (Lindgren et al., 1982). Although the study authors measured radioactive arsenic (^74^As) in the various tissues, they did not differentiate between the different species of arsenic and could not determine if accumulation was due to the originally administered compound or metabolites. Arsenic levels in all these tissues, with the exception of the skeleton, were greater in mice administered As^III^ than in mice administered As^V^. This could indicate that As^III^ is taken up more efficiently than As^V^ and that less was found in the tissues of As^V^-treated mice due to the initial reduction to As^III^. The calcified areas of the skeleton in mice administered As^V^ accumulated and retained more arsenic than mice administered As^III^, most likely due to the similarities between As^V^ and phosphate, causing a substitution of phosphate by As^V^ in the apatite crystals in bone. Marmoset monkeys were found not to accumulate arsenic in the ocular lens or the thyroid (Vahter et al., 1982) following intraperitoneal injection of arsenite; however, intravenous administration of ^74^As-labelled DMA to mice resulted in accumulation of DMA in the ocular lens and the thyroid. Marmoset monkeys do not methylate arsenic, and DMA was found to accumulate in the ocular lens and thyroid of mice; this suggests that only the methylated species are retained in these organs. Mouse tissues with the largest retention of DMA were the lens of the eyes, thyroid, lungs, and intestinal mucosa (Vahter et al., 1984). Methylated arsenic species (DMA), in general, have a shorter tissue retention time in mice than rats (i.e., more than 99% of the administered dose was eliminated in mice within 3 days as compared to 50% in rats due to accumulation in blood) (Vahter et al., 1984).

Hughes et al. (2003) estimated that a steady-state, whole-body arsenic balance was established after nine repeated oral daily doses of 0.5 mg As/kg as radioactive As^V^ in adult female B6C3F1 mice. Twenty-four hours after the last dose, the whole-body burden of arsenic was about twice that observed after a single dose. The rate of elimination was slower following repeated doses. Accumulation of radioactivity was highest in the bladder, kidney, and skin, while the loss of radioactivity was greatest from the lungs and slowest from the skin. Atomic absorption spectrometry was used to characterize the organ distribution of arsenic species. MMA was detected in all tissues except the bladder. DMA was found at the highest levels in the bladder and lung after a single oral exposure, with increases after repeated exposures. Inorganic arsenic was predominantly found in the kidney. After a single oral exposure of As^V^ (0.5 mg As/kg), DMA was the predominant form of arsenic in the liver, but after nine repeat exposures, the proportion of DMA decreased while the proportion of inorganic arsenic increased (this could indicate metabolic saturation or GSH depletion; see Section 3.3 for more details). A trimethylated form of arsenic also was detected in the liver.

Kenyon et al. (2005) examined the time course of tissue distribution of different arsenic species after a single oral dose of 0, 10, or 100 μmole As/kg as sodium arsenate to adult female B6C3F1 mice. The concentrations of all forms of arsenic were lower in the blood than in other organs across all doses and time points. The concentration of inorganic arsenic measured in the liver was similar to that measured in the kidney at both dose levels, with peak concentrations observed 1 hour after dosing. For the first 1 to 2 hours, inorganic arsenic was the predominant form in both the liver and kidney, regardless of dose. At the later times, DMA became the predominant form. Kidney measurements 1 hour after dosing demonstrated that MMA levels were 3 to 4 times higher than in other tissues. DMA concentrations in the kidney reached their peak 2 hours after dosing. DMA was the predominant form measured in the lungs at all time points following exposure to 10 μmole As/kg as As^V^. DMA concentrations in the lung were greater than or equal to those of the other tissues beginning at four hours. The study did not distinguish the different valence states of the MMA or DMA compounds.

In a follow-up study by Kenyon et al. (2008), adult female C57BL/6 mice were administered 0, 0.5, 2, 10, or 50 ppm of arsenic as sodium arsenate in the drinking water for 12 weeks. The average daily intakes were estimated to be 0, 0.083, 0.35, 1.89, and 7.02 mg As/kg/day, respectively. After 12 weeks of exposure, the tissue distributions were as follows: kidney > lung > urinary bladder > skin > blood > liver. In the kidney, MMA was the predominant form measured, while DMA was more prominent in the lungs and blood. The skin and urinary bladder had nearly equal levels of both inorganic arsenic and DMA and the liver had equal proportions of all three species.

Naranmandura et al. (2007) characterized the tissue distribution in rats and hamsters administered a single oral dose of As^III^ (5.0 mg As/kg body weight, or BW). In rats, the highest concentrations were found in RBCs. Because hamsters did not accumulate arsenic species in their RBCs, they exhibited a more uniform tissue distribution. While the quantity of arsenic in the liver and kidneys of the hamster were significantly greater than those observed in the rat, arsenic accumulated more and was retained longer in the kidneys than the liver in both species. The hamster had greater levels of MMA^III^ bound to protein in the kidney than rats.

As^III^ and As^V^, as well as methylated metabolites, cross the placenta at all stages of gestation in mice, marmoset monkeys, and hamsters (Lindgren et al., 1984; Jin et al., 2006; Hood et al., 1987; Hanlon and Ferm, 1977), with tissue distribution of arsenic similar between the mother and the fetus in late gestation. Jin et al. (2006) found increased levels of inorganic arsenic and DMA in the livers and brains of newborn mice from dams administered either As^III^ or As^V^ in their drinking water throughout gestation and lactation. The levels of total arsenic in the mothers’ livers increased in a dose-dependent manner and were greater than those observed in the mothers’ brains or in the newborns’ brains or livers. The levels of total arsenic in the livers and brains of newborn mice, however, were greater than those observed in the mothers’ brains, suggesting easier passage through the placenta than through a mature blood-brain barrier. Because the levels of inorganic arsenic in the newborn livers and brains were nearly identical, it appears that there was no difficulty in passing through an immature blood-brain barrier. In addition, the nearly 2:1 ratio of DMA in the brains compared to the livers of newborns indicates either a preferential distribution of DMA in the newborns’ brains or an increased distribution of inorganic arsenic to the brain that is subsequently metabolized. The marmoset monkey (known to not methylate arsenic) displayed somewhat less placental transfer after administration of As^III^ than was seen in mice (Lindgren et al., 1984).

The arsenic concentration in the cord blood (11 μg/L) was similar to that observed in maternal blood (an average of 9 μg/L) in pregnant women living in a village in northwestern Argentina, where the arsenic concentration in the drinking water was approximately 200 ppb (Concha et al., 1998b). Hall et al. (2007) also found a strong association between maternal (11.9 μg/L) and cord blood levels (15.7 μg/L) in Matlab, Bangladesh (arsenic exposure ranged from 0.1 to 661 ppb in drinking water). They also measured arsenic metabolite levels and found that the association also was observed for the metabolites MMA and DMA. Elevated arsenic concentrations also were noted in pregnant women living in cities with low dust fall (i.e., low arsenic inhalation exposures), where an average of 3 μg/L was measured in the maternal blood and 2 μg/L in cord blood (Kagey et al., 1977). Women living near smelters also have been observed to have an increased concentration of placental arsenic (Tabacova et al., 1994). Although the human fetus is exposed to arsenic, it may be more in the form of DMA (at least in late gestation) because 90% or more of the arsenic in the urine and plasma of newborns and mothers (at time of delivery) was DMA.

### D.1.5 Cellular Uptake, Distribution, and Transport

Cellular uptake of inorganic arsenic compounds also depends on oxidation state, with As^III^ generally being taken up at a much greater rate than arsenate (Cohen et al., 2006). In Chinese hamster ovary (CHO) cells, the rate of uptake was DMA^III^ > MMA^III^ > As^III^ (Dopp et al., 2004), with the pentavalent forms being taken up much more slowly than the trivalent forms. Delnomdedieu et al. (1995) demonstrated that As^III^ is taken up more readily than As^V^, MMA^V^, or DMA^V^ by RBCs in rabbits. Drobna et al. (2005) found that MMA^III^ and DMA^III^ were taken up by modified UROtsa cells expressing arsenic methyltransferase (this is a human urothelial cell line that normally does not methylate inorganic arsenic) at an order of magnitude faster than As^III^. Because arsenate uptake is inhibited in a dose-dependent manner by phosphate (Huang and Lee, 1996), it has been suggested that a common transport system is responsible for the cellular uptake for both compounds. As^III^ uptake, however, is not affected by phosphate; therefore, Huang and Lee (1996) suggested that cellular uptake of As^III^ occurs through simple diffusion. Liu et al. (2002) and Liu et al. (2006a), however, suggested that transport of As^III^ and MMA^III^ across the cellular membrane may be mediated by AQP7 and AQP9 with MMA^III^ transported at a higher rate. Lu et al. (2006) found that inorganic arsenic (both pentavalent and trivalent oxidation states) can be transported by organic anion transporting polypeptide-C (OATP-C, which was transfected into cells of a human embryonic kidney cell line), but not MMA^V^ or DMA^V^. In a cell line resistant to arsenic (R15), Lee et al. (2006) found little AQP7 or AQP9 messenger RNA (mRNA) and only half the AQP3 mRNA expression compared to the parental cell line (CL3, a human lung adenocarcinoma cell line). Suppressing the AQP3 expression in CL3 cells caused less arsenic to accumulate in these cells. Over-expression of AQP3 in a 293 cell line (a human embryonic kidney cell line) resulted in an increase in arsenic accumulation in the cells. Hexose permease transporters (HXT) also have been suggested as another influx pathway for As^III^ (Thomas, 2007).

Shiobara et al. (2001) demonstrated that the uptake of DMA in RBCs was dependent on not only the chemical form (or oxidation state), but animal species. DMA^III^ and DMA^V^ were incubated with rat, hamster, mouse, and human RBCs. DMA^V^ was only minimally absorbed by RBCs, and the cellular uptake was very slow in all animal species tested. DMA^III^, on the other hand, was efficiently taken up by the RBCs in the following order: rats > hamsters > humans. Mouse RBCs were less efficient at the uptake of DMA^III^ than any of the other species. Rat RBCs retained the DMA^III^ throughout the 4 hours of the experiment, but hamster RBCs were found to excrete the arsenic absorbed as DMA^III^ in the form of DMA^V^. Human RBCs also excreted DMA^III^ as DMA^V^, though the rate of uptake of DMA^III^ and efflux of DMA^V^ was much slower than in hamster RBCs.

Cellular excretion of arsenic species also depends on oxidation state and the degree of methylation. Leslie et al. (2004), using membrane vesicles from a multi-drug resistant human lung cancer cell line (H69AR), found that a multi-drug resistance protein (MRP) called MRP1 transports As^III^ in the presence of GSH but did not transport As^V^ under any conditions. This suggests that As^V^ must be reduced to As^III^ before being excreted from the cell. Further, the MRP1 transport was more efficient with arsenic triglutathione (ATG) as the substrate. This finding, along with the observation that As^III^ transport is more efficient at neutral or low pH where ATG is more readily formed and more stable, suggests that ATG is formed prior to transport. Leslie et al. (2004) also suggest that the formation of the conjugate is catalyzed by the glutathione-S-transferase P1-1 (GSTP1-1) enzyme. MRP2 may also be involved in the efflux of arsenic species from cells (Thomas, 2007). MRP2 expression was found to be five times higher in arsenic resistant (R15) cells compared to the parent cell line (CL3). However, expression levels of MRP1 and MRP3 were similar to levels in parent cells (Lee et al., 2006). Suppressing the multi-drug resistant transporters reduced the efflux of arsenic from R15 cells.

In a study of rabbits and mice exposed to radio-labeled As^III^, the majority of the arsenic was found in the nuclear and soluble fractions of liver, kidney, and lung cells (Marafante et al., 1981; Marafante and Vahter, 1984). The marmoset monkey had a different intracellular distribution, with approximately 50% of the arsenic dose found in the microsomal fraction in the liver (Vahter et al., 1982; Vahter and Marafante, 1985). Chemical inhibition of arsenic methylation in rabbits did not alter the intracellular distribution of arsenic (Marafante and Vahter, 1984; Marafante et al., 1985).

Increases in tissue arsenic concentration (especially in the liver) have been found to be associated with increased arsenic concentrations in the microsomal fraction of the liver in rabbits fed diets containing low concentrations of methionine, choline, or proteins, which leads to decreased arsenic methylation (Vahter and Marafante, 1987). The levels of arsenic in the microsomal fraction of the liver in these rabbits were similar to those observed in the marmoset monkey (Vahter et al., 1982), indicating that nutritional factors may play a role in determining the subcellular distribution of arsenic.

### D.1.6 Metabolism

After entering the body, As^V^ can be reduced to As^III^, which can then proceed through a series of methylation and conjugation reactions, some of which involve re-oxidation of arsenic to As^V^. The traditional metabolic pathways proposed for arsenic are shown in Figure D-1. In this metabolic scheme, less toxic species (i.e., As^V^, MMA^V^, and DMA^V^) can be converted to more toxic species (i.e., As^III^, MMA^III^, and DMA^III^). The trivalent species have been found to be more cytotoxic, genotoxic, and more potent inhibitors of enzyme activity (Thomas et al., 2001). While the final metabolite in humans is predominantly DMA^V^, as this is the form most highly excreted, some animal species further metabolize DMA^V^ through DMA^III^ to trimethylarsine oxide (TMAO).

Figure D-1 Traditional metabolic pathway for inorganic arsenic in humans

Source: Sams et al. (2007).

Hayakawa et al. (2005) suggested a possible alternate metabolic pathway for inorganic arsenic (see Figure D-2). As in the previously described model, the first step involves reduction of As^V^ to As^III^. A major difference, however, is that Hayakawa et al. (2005) suggest that arsenic-glutathione complexes are important intermediates in the metabolism of arsenic and are the primary substrates for arsenic methyltransferases. The proposed model was based on the observation that more DMA^V^ is produced from As^III^ than from MMA^V^. This should not be the case if the reactions depicted in Figure D-1 are the primary arsenic metabolic pathways. Their data suggest that arsenite, in the presence of GSH, non-enzymatically reacts to form ATG. In support of this mechanism, they observed a dose-dependent increase in concentration of ATG with increasing doses of GSH, up to 4 mM. Monomethyl and dimethyl arsenic species were generated by the transfer of a methyl group from SAM in the presence of human recombinant arsenic (+3 oxidation state) methyltransferase (AS3MT), and only occurred when ATG or monomethylarsonic diglutathione (MADG) was present. At concentrations of glutathione of 2.0 mM or greater, there was a dose-dependent increase in DMA^V^ levels, accompanied by a dose-dependent decrease in As^V^.

Figure D-2 Alternative metabolic pathway for inorganic arsenic in humans proposed by Hayakawa et al. (2005)

In summary, the proposed metabolic model of Hayakawa et al. (2005) suggests that As^V^ is first reduced to As^III^, which then reacts (non-enzymatically) with GSH (producing ATG). In the presence of AS3MT (specified as cyt19 in the Hayakawa article),^42^ ATG is methylated to MADG if the GSH concentration is sufficient, which then comes to equilibrium with MMA^III^ (GSH concentrations lower than 1 mM caused MADG to be unstable in solution and was readily hydrolyzed and oxidized to MMA^V^). While some of the MMA^III^ is oxidized to MMA^V^, some of the MADG is methylated by AS3MT to dimethylarsinic glutathione (DMAG), which, like MADG, is in equilibrium with its trivalent form and can be oxidized to its pentavalent form. This more recently proposed pathway leads to higher proportions of less toxic final species than the original proposed metabolic pathway (see Figure D-1).

Results reported by Hughes et al. (2005) may provide support for the Hayakawa et al. (2005) revised pathway. B6C3F1 mice administered MMA^V^ by oral gavage demonstrated its rapid absorption, distribution, and excretion, with 80% of the dose eliminated within 8 hours. Very little of the absorbed dose, however, was methylated to DMA and/or TMAO. Less than 10% of the dose excreted in urine and 25% or less of the dose measured in the tissues were in the form of DMA. In contrast, in MMA^III^-treated mice, more than 90% of the excreted dose and more than 75% of the arsenic measured in the tissues was identified as DMA. This discrepancy between the two forms of MMA is not expected if the generally accepted metabolic pathway (see Figure D-1) is followed. However, if MMA^III^ is the form methylated to DMA while MMA^V^ is an end product, as is suggested by Hayakawa et al. (2005), then it would be expected that a greater proportion of MMA^III^ would be methylated to DMA than MMA^V^. There are, however, factors that may limit the in vivo methylation of MMA^V^ that are unrelated to the metabolic pathway proposed by Hayakawa et al. (2005). First, MMA^V^ does not appear to be taken up well by the liver (Hughes et al., 2005), a major site of inorganic arsenic metabolism (Thomas et al., 2001). In fact, pentavalent species of arsenic are not taken up by cells as readily as trivalent arsenicals (Dopp et al., 2004). In addition, in the generally accepted metabolic pathway (see Figure D-1), MMA^V^ needs to be reduced to MMA^III^ in order to be methylated. Therefore, if very little is taken up into cells, very little can be methylated.

Aposhian and Aposhian (2006) suggest that it is too early to accept AS3MT as the primary methyltransferase responsible for arsenic methylation in humans because it has only been observed in experiments involving deoxyribonucleic acid (DNA) recombinant technology and because there is no indication that the enzyme is expressed in human liver. Although AS3MT has been detected in human liver cell lines (Zakharyan et al., 1999), it has not been isolated from surgically removed liver tissue. Thomas (2007) also states the evidence supports the conclusion that arsenic methylation catalyzed by AS3MT is not strictly dependent on the presence of GSH, which would suggest that other pathways may be involved in addition to those included in Hayakawa et al. (2005) model. GSH depletion would likely occur at high arsenic exposures under Hayakawa et al. (2005) proposed pathway. Therefore, it is possible that both pathways work in conjunction, or one is predominant over the other depending on the concentration of arsenic. Hayakawa et al. (2005) found that levels of MMA^V^ were not dependent on GSH level (from 2 to 5 mM), suggesting that this indicated possible further methylation to DMA^V^. Since this is not part of the proposed Hayakawa et al. (2005) pathway, at least some of the MMA^V^ may be methylated through the classic pathway.

### D.1.7 Reduction

A substantial fraction of absorbed As^V^ is rapidly reduced to As^III^ in most species studied; in mice, rabbits, and marmoset monkeys, the reduction apparently occurs mainly in the blood (Vahter and Envall, 1983; Vahter and Marafante, 1985; Marafante et al., 1985). Reduction also may occur in the stomach or intestines prior to absorption, but quantitative experimental data are not available to determine the importance of this GI reduction. In addition to the reduction of inorganic As^V^, as shown in Figure D-1, methylated As^V^ species also may be reduced by different enzymes.

GSH may play a role in the reduction of As^V^, but is not the only cofactor, as cysteine and dithiothreitol (DTT) also have been found to reduce As^V^ to As^III^ in vitro (Zakharyan et al., 1995; NRC, 1999; Németi and Gregus, 2002). Inorganic phosphate inhibits the formation of As^III^ from As^V^ in intact RBCs (Németi and Gregus, 2004), probably by competing with the phosphate transporter for the uptake into cells.

Arsenate reductase enzymes have been detected in the human liver (Radabaugh and Aposhian, 2000). At least one of these enzymes has been characterized as a purine nucleoside phosphorylase (PNP) (Radabaugh et al., 2002; Gregus and Németi, 2002). This enzyme requires a thiol and a heat-stable cofactor for activation. According to Radabaugh et al. (2002), dihydrolipoic acid (DHLP) is the most active naturally occurring thiol in mammalian systems and appears to be required for the enzymatic reduction of As^V^ to As^III^. PNP, however, did not catalyze the reduction of MMA^V^ to MMA^III^. An MMA^V^ reductase has been detected in rabbit liver (Zakharyan and Aposhian, 1999), hamster tissues (Sampayo-Reyes et al., 2000), and human liver (Zakharyan et al., 2001). In humans, this reductase is human glutathione-S-transferase ω (hGST-O1), which is a member of the glutathione-S-transferase (GST) superfamily (Aposhian and Aposhian, 2006).

Although PNP has been determined to reduce As^V^ to As^III^, Nemeti et al. (2003) observed this reduction only in vitro. PNP did not appear to be a major player in the reduction of As^V^ to As^III^ in either human erythrocytes or in rats in vivo. Németi and Gregus (2004) and Németi and Gregus (2005) further demonstrated that human erythrocytes exhibit a PNP-independent As^V^-reducing pathway that requires GSH, nicotinamide adenine dinucleotide (NAD), and a substrate for either one or both of the following enzymes: glyceraldehyde-3-phosphate dehydrogenase (GAPDH) or phosphoglycerate kinase (PGK). This mechanism of reduction also was demonstrated in rat liver cytosol (Németi and Gregus, 2005). In addition, another unidentified enzyme in the liver cytosol had the capacity to reduce As^V^. A further study (Gregus and Németi, 2005) demonstrated that GAPDH exhibited As^V^ reductase activity, but that PGK served as an auxiliary enzyme when 3-phosphoglycerate was the glycolic substrate.

The reduction of pentavalent arsenicals also has been observed to be catalyzed by AS3MT (Waters et al., 2004b). According to Waters et al. (2004a), AS3MT may possess both As^III^ methyltransferase and As^V^ reductase activities. In the presence of an exogenous or physiological reductant, AS3MT was found to catalyze the entire sequence converting arsenite to all of its methylated metabolites through both methylation and reduction steps (see Figure D-1). Thomas (2007) also suggest that thioredoxin (Trx, isolated from E. coli) is necessary, possibly reducing some critical cysteine residue in AS3MT as a step in the methyltransferase reaction. Cohen et al. (2006) suggest that Trx, thioredoxin reductase (TrxR), and nicotinamide adenine dinucleotide phosphate-oxidase (NADPH) are the primary reducing agents involved in the conversion of MMA^V^ to DMA^V^, but they are orders of magnitude less effective than the arsenic methyltransferase isolated from rabbit liver (i.e., AS3MT). Zakharyan and Aposhian (1999) found that MMA^V^-reductase was the rate-limiting enzyme in arsenic biotransformation in rabbit livers. Jin et al. (2006) also suggest that As^V^ reduction is possibly a rate-limiting step in arsenic metabolism at low concentrations. At higher concentrations, saturation or methylation inhibition may cause other reactions to become rate-limiting.

### D.1.8 Arsenic Methylation

Methylation is an important factor affecting arsenic tissue distribution and excretion. Humans and most experimental animal models methylate inorganic arsenic to MMA and DMA, with the amounts differing across species, as determined by analysis of urinary metabolites. The methylated metabolites in and of themselves have historically been considered less acutely toxic, less reactive with tissue constituents, less cytotoxic, and more readily excreted in the urine than inorganic arsenic (Yamauchi and Yamamura, 1984; Vahter and Marafante, 1983; Vahter et al., 1984; Sakurai et al., 1998; Rasmussen and Menzel, 1997; Moore et al., 1997; Marafante et al., 1987;Hughes and Kenyon, 1998). The trivalent species MMA^III^ and DMA^III^, however, have been demonstrated to be more cytotoxic in a human liver cell line called Chang cells (Petrick et al., 2000; Petrick et al., 2001), CHO (Dopp et al., 2004), and cultured primary rat hepatocytes (Styblo et al., 1999; Styblo et al., 2000) than As^III^, As^V^, MMA^V^, or DMA^V^.

Although the kinetics of arsenic methylation in vivo are not fully understood, it is believed the liver may be the primary site of arsenic methylation. However, the testes, kidney, and lung also have been observed to have a high methylating capacity (Cohen et al., 2006). Marafante et al. (1985) found that DMA appeared in the liver prior to any other tissue in rabbits exposed to inorganic As. It also has been demonstrated oral administration of inorganic arsenic favors methylation more than either subcutaneous or intravenous administration (Vahter, 1981; Charbonneau et al., 1979; Buchet et al., 1984), presumably because the arsenic will pass through the liver first after oral administration. However, liver disease (i.e., alcoholic, post-necrotic or biliary cirrhosis, chronic hepatitis, hemochromatosis, and steatosis) can be associated with increased ratios of DMA to MMA in the urine following a single injection of sodium arsenite (Geubel et al., 1988; Buchet et al., 1984). This appears to indicate that efficient methylation of arsenic continues in the presence of liver damage, possibly indicating that a different organ is responsible for methylation under these circumstances. In addition, the site of methylation may depend on the rate of reduction of As^V^ to As^III^. Isolated rat hepatocytes readily absorbed and methylated As^III^, but not As^V^ (Lerman et al., 1983). Kidney slices, on the other hand, produced five times more DMA from As^V^ than As^III^ (Lerman and Clarkson, 1983). Therefore, it is likely that any As^V^ not initially reduced can be efficiently methylated in the kidney for subsequent urinary excretion.

Identifying the main organs responsible for methylation of arsenic in vivo has not been straightforward because in vitro results do not necessarily reflect in vivo methylation patterns (NRC, 1999). Buchet and Lauwerys (1985) identified the rat liver as the main organ for methylation, with the methylating capacities in the RBCs, brain, lung, intestine, and kidneys being insignificant in comparison. Assays of arsenite methyltransferases from mouse tissues demonstrated the testes had the highest methylating activity, followed by the kidney, lung, and liver (Healy et al., 1998). Aposhian (1997) determined that the amount of methyltransferases vary in the liver of different animal species. Arsenite bound to components of tissue can be methylated and released (Vahter and Marafante, 1983; Marafante et al., 1981). This may explain the initial rapid phase (immediate methylation and excretion) followed by a slow elimination phase (continuous release of bound arsenite through methylation) (NRC, 1999), as described in Section 3.1.

It has been demonstrated that inhibition of arsenic methylation results in increased tissue concentrations of arsenic (Marafante and Vahter, 1984; Marafante et al., 1985). Loffredo et al. (2003) suggest that the second methylation step is inducible and that the inducibility is possibly polymorphic (i.e., more than one enzyme or enzyme form may be involved, depending on the individual). This suggestion is based on observations that human urinary DMA concentrations in high-exposure groups were higher and more variable than urinary MMA levels, and because urinary DMA levels appeared to have a bimodal distribution in a population from Mexico, regardless of exposure status. Others have suggested that the second methylation step may be saturable, which would be consistent with the decreasing excretion of DMA with increasing arsenic exposures (Ahsan et al., 2007). Cysteine, GSH, and DTT have been shown to increase the activity of arsenite methyltransferase and MMA methyltransferase (both later identified as AS3MT) (Lin et al., 2002) in purified rabbit liver enzyme preparations (Zakharyan et al., 1995). Dithiols (e.g., reduced lipoic acid) have also been found to enhance arsenite methylation by MMA^III^ methyltransferase (Zakharyan et al., 1999). Glutathione-S-transferase omega 1 (GSTO1) has also been associated with arsenic biotransformation (Meza et al., 2007). Although humans have been observed to methylate arsenic, no arsenic methyltransferase has yet been isolated from human tissues (Aposhian and Aposhian, 2006).

In vitro studies using rat liver preparations indicate that the methylating activity is localized in the cytosol, with SAM being the main methyl donor for As^III^ methylation (Zakharyan et al., 1995; Styblo et al., 1995; Styblo et al., 1996; Marafante and Vahter, 1984; Marafante et al., 1985; Buchet and Lauwerys, 1985). AS3MT catalyzes the transfer of the methyl group from SAM to the arsenic substrates (Thomas, 2007; Lin et al., 2002). Expressing AS3MT in UROtsa (human urothelial cells that do not normally methylate inorganic arsenic) caused the cells to effectively methylate arsenite (Drobna et al., 2005). High concentrations of As^III^ or MMA^III^ in the culture caused an inhibition in the formation of DMA but had little effect on the formation of MMA. The inhibition of DMA production resulted in MMA accumulation in cells. Drobna et al. (2006) demonstrated that AS3MT was the major enzyme for arsenic methylation in human hepatocellular carcinoma (HepG2) cells but reducing it by 88% (protein levels) only accounted for a 70% reduction in methylation capacity, suggesting that there is another methylation process that is independent of AS3MT.

The addition of GSH has been found to increase the yield of mono- and dimethylated arsenicals but suppressed the production of TMAO in the presence of rat AS3MT (Waters et al., 2004b), indicating that GSH suppresses the third methylation reaction but not the first two (Thomas, 2007). Thomas et al. (2004) discovered a similar arsenic methyltransferase in the rat liver, which they designated cyt19 because an orthologous cyt19 gene encodes an arsenic methyltransferase in the mouse and human genome. It has subsequently been concluded that this methyltransferase was the same as AS3MT.

GSH alone does not support recombinant rat AS3MT catalytic function, but when added to a reaction mixture containing other reductants, the rate of arsenic methylation increases (Waters et al., 2004a). GSH alone (5mM) does not support the catalytic activity of AS3MT, but stimulates the methylation rate in the presence of the reductant tris(2-carboxylethyl)phosphine (TCEP; 1 mM) (Thomas, 2007). GSH (5 mM) did not have any effect on DTT (1 mM)-induced arsenic methylation. Drobna et al. (2004) linked the genetic polymorphism of AS3MT with other cellular factors and to the inter-individual variability in the capacity of primary human hepatocytes to retain and metabolize As^III^.

The main products of arsenic methylation in humans are MMA^V^ and DMA^V^, which are readily excreted in the urine (Marcus and Rispin, 1988). MMA^III^ and DMA^III^ have recently been detected in human urine (NRC, 2001); however, most studies do not differentiate the valence state of mono- or dimethylated arsenic species detected in urine or tissue samples. Le et al. (2000a), Le et al. (2000b) and Del Razo et al. (2001) noted that the concentration of trivalent metabolites in the urine may be underestimated because they are easily oxidized after collection. Le et al. (2000b) found 43 to 227 μg/L of MMA^III^ in the urine of populations from Inner Mongolia, China, who were exposed to 510–660 ppb (0.46 μM) of arsenic via the drinking water.

A small percentage of DMA^III^ may further be methylated to TMAO in mice and hamsters (see Kenyon and Hughes, (2001) for a review). A single human volunteer ingesting DMA excreted 3.5% of the dose as TMAO (Kenyon and Hughes, 2001). TMAO can be detected in urine following DMA exposure, but has not been detected in the blood or tissues of mice exposed intravenously to DMA (Hughes et al., 2000) or in the urine of mammals orally exposed to inorganic As. This may be due to rapid clearance of DMA and MMA from cells (Styblo et al., 1999) however, most analytical methods are not optimized for the detection of TMAO that could have been present but not detected.

### D.1.9 Species Differences in the Methylation of Arsenic

There is considerable variation in the patterns of inorganic arsenic methylation among mammalian species (NRC, 1999). Humans, rats, mice, dogs, rabbits, and hamsters have been shown to efficiently methylate inorganic arsenic to MMA and/or DMA. Rats and hamsters appear to methylate administered DMA into TMAO more efficiently than other species (Yamauchi and Yamamura, 1984; NRC, 1999). About 40% of urinary arsenic was present as TMAO 1 week after exposure to DMA in the drinking water, while 24% was present as TMAO after 7 months of exposure (100 mg/L) in male rats (Yoshida et al., 1998).

Humans (mainly exposed to background levels or exposed at work) have been estimated through a number of studies to excrete 10% to 30% of the arsenic in its inorganic form, 10% to 20% as MMA, and 55% to 75% as DMA (see Vahter (1999a) for a review). In contrast, a study of urinary arsenic metabolites in a population from northern Argentina exposed to arsenic via drinking water demonstrated an average of only 2% MMA in the urine (Vahter et al., 1995a; Concha et al., 1998a). This may indicate variations in methylation activity depending on the route of exposure, level of exposure, and possible nutritional or genetic factors. Although humans are considered efficient at arsenic methylation, they are less efficient than many animal models, as indicated by the larger proportion of MMA^V^ excreted in the urine (Vahter, 1999a). This is important because it may explain why humans are more susceptible to cancer from arsenic exposures, and why no adult animal model for inorganic-arsenic-induced cancers has yet been identified (Tseng et al., 2005).

The rabbit (Vahter and Marafante, 1983; Marafante et al., 1981; Maiorino and Aposhian, 1985) and hamster (Yamauchi and Yamamura, 1984; Marafante and Vahter, 1987; Charbonneau et al., 1980) appear to be more comparable to humans with respect to arsenic methylation than other experimental animals (NRC, 1999). However, rabbits and hamsters, in general, excrete more DMA and less MMA than humans. In contrast, Flemish giant rabbits (De Kimpe et al., 1996) excrete MMA in amounts similar to humans. Mice and dogs, efficient methylators of arsenic, excrete more than 80% of a single arsenic dose administered as DMA within a few days (Vahter, 1981; Charbonneau et al., 1979). Guinea pigs (Healy et al., 1997), marmoset monkeys (Vahter et al., 1982; Vahter and Marafante, 1985), and chimpanzees (Vahter et al., 1995b), on the other hand, do not appear to appreciably methylate inorganic arsenic. In addition, no methyltransferase activity was detected in these species (Zakharyan et al., 1995; Zakharyan et al., 1996; Vahter, 1999a; Healy et al., 1997). Li et al. (2005) identified a frameshift mutation in the chimpanzee AS3MT gene that resulted in the production of an inactive truncated protein, possibly explaining the lack of methylation activity in that species.

AS3MT homolog proteins with five fully conserved cysteine residues have been observed in the genome of numerous species (Thomas, 2007). Chimpanzees were found to differ from other species studied in that their AS3MT protein was shorter and lacked the 5th cysteine (Thomas, 2007). Healy et al. (1999) identified marked variations in the activity of methyltransferases, while Vahter (1999b) characterized differences in methylation efficiency among different human populations. The observed variations in methyltransferase activity and methylation efficiency are probably the underlying reason for the cross-species variability in methylation ability, as all the species had ample arsenate reductase activity (Vahter, 1999a; NRC, 2001).

Although arsenic methylation is generally believed to take place in order to enhance excretion, there are several species (guinea pigs, marmoset monkeys, and chimpanzees) that do not methylate arsenic, but still efficiently excrete it. In fact, these animals do not retain arsenic any longer than species that methylate arsenic (Cohen et al., 2006), indicating that factors other than methylation also affect arsenic excretion rates. Supporting this is the fact that inorganic arsenic is found in the urine of even the most efficient methylators (Vahter, 1994).

### D.1.10 Thioarsenical Metabolites

In 2004, Hansen et al. (2004) reported the detection of unusual arsenic-containing metabolites in the urine of sheep exposed to arsenic-contaminated vegetation. The metabolite was tentatively identified as dimethylmonothioarsinic acid (DMMTA^III^), a sulfur-containing derivative of DMA^III^ as shown in Figure D-3. Because the exposed sheep consumed algae known to contain arsenosugars, some of which contain sulfur, the relevance of this finding to human exposures was not initially clear. Subsequently, Raml et al. (2006) detected the presence of DMMTA^III^ in the urine of Japanese men, but again, consumption of arsenosugars was suspected as a source of the observed arsenic containing species.

Figure D-3 Thioarsenical structures

Source: Hansen et al. (2004).

In experiments addressing this issue, Adair et al. (2007) and Naranmandura et al. (2007) found substantial concentrations of thioarsenical metabolites in arsenic-exposed experimental animals. Adair et al. (2007) administered drinking water containing 100 ppm As^V^ or up to 200 ppm DMA^III^ to female Fisher 344 rats for 14 days. During analysis of the urine (collected during the last 24 hours of exposure) for metabolites, they found high levels of DMMTA^III^ and trimethylarsine sulfide (another sulfur-containing metabolite) in the urine of rats treated with DMA^III^. Lower levels of the sulfur-containing metabolites were detected in the urine of arsenate-treated animals. They proposed a mechanism whereby the reaction of DMA^III^ and DMA^V^ with hydrogen sulfide resulted in the observed metabolites.

Naranmandura et al. (2007) administered single doses of 5.0 mg/kg As^III^ to Syrian hamsters and Wistar rats by gavage and measured the levels of sulfur-containing arsenic metabolites in urine. Both DMMTA^III^ and dimethylmonothioarsonic acid (DMMTA^V^) were found at appreciable levels in urine from hamsters, but only the latter metabolite was found in rat urine. A previously uncharacterized metabolite, monomethylmonothioarsonic acid, was also found in urine from both species.

These studies suggest that the generation of sulfur-containing arsenic metabolites does not depend on exposures to arsenosugars, at least in rodents, but can occur during the metabolism of inorganic arsenic compounds. In 2007, Raml et al. (2007) presented evidence that this pathway was also significant in humans. DMMTA^III^ was detected in the urine of 44% (33 of 75) women exposed to inorganic arsenic-contaminated drinking water in Bangladesh. The metabolite was present in urine samples at concentrations between “trace” amounts and 24 μg/L, with total arsenic concentrations ranging from 8 to 1034 μg/L. It was suggested that thioarsenical metabolites may have been present in urine from other epidemiological studies of arsenic-exposed populations but may have not been detected due to analytical difficulties.

## D.2 ELIMINATION

The major route of excretion for most arsenic compounds by humans is via urine (Yamauchi and Yamamura, 1979; Tam et al., 1979; Pomroy et al., 1980; Buchet et al., 1981). Six human subjects who ingested 0.01 μg of radio-labeled ^74^As^V^ excreted an average of 38% of the administered dose in the urine within 48 hours and 58% within 5 days (Tam et al., 1979). Inorganic arsenic elimination in humans has been observed to be triphasic, with first-order half-lives for elimination of 1 hour, 30 hours, and 200 hours: Mealey et al. (1959) used AsIII, Pomroy et al. (1980) used AsV.

As mentioned in the preceding section, MMA and DMA are metabolites generated after exposure to inorganic arsenic. These methylated metabolites are excreted in the urine faster than inorganic arsenic. In humans orally exposed to MMA or DMA in aqueous solution, about 78% of MMA and 75% of DMA were excreted in the urine within 4 days of ingestion (Buchet et al., 1981). In mice, the half-time of MMA and DMA excretion was found to be about 2 hours following iv administration (Hughes and Kenyon, 1998).

Kenyon et al. (2008) administered 0, 0.5, 2, 10, or 50 ppm of arsenic as sodium arsenate to adult C57Bl/6 female mice in the drinking water for 12 weeks. The average daily intakes were estimated to be 0, 0.083, 0.35, 1.89, and 7.02 mg As/kg-day, respectively. Levels of MMA^III^, DMA^III^, DMA^V^, and TMAO in the urine collected at the end of treatment increased in a linear manner with dose, but As^V^ and MMA^V^ did not.

Rats excrete DMA slowly compared to other species (Vahter et al., 1984), even though they are efficient at methylating inorganic arsenic to DMA. The slow excretion is believed to be associated with retention of a significant portion of the DMA in erythrocytes (Vahter, 1983; Vahter et al., 1984; Odanaka et al., 1980; Lerman and Clarkson, 1983). The biliary excretion of inorganic arsenic by rats is about 800 times greater than observed in dogs and 37 times that of rabbits, as proportion of administered dose. Hughes et al. (2005) found that in mice the level of MMA^V^ excreted in the urine compared to the bile was related to dose, with fecal excretion increasing at higher doses. Cui et al. (2004) also found that rat biliary excretion rates varied with dose, but found it was also related to route of administration and chemical form. After oral administration of inorganic arsenic (either form) to male Sprague-Dawley rats, MADG and DMA^V^ (likely present due to dissociation of DMAG) were the predominant forms in the bile. MADG was found at a higher level after a higher (i.e., 100 ppm) dose, while DMA^V^ was more prevalent at the lower dose (i.e., 10 ppm). Kala et al. (2000) found that the secretion of arsenic into the bile of rats was dependent on the multi-drug resistance-associated protein 2 transporter (MPR2/cMOAT) and that GSH is necessary for the transport, as arsenic-glutathione complexes accounted for the majority of arsenic found in the bile.

Although absorbed arsenic is removed from the body mainly via the urine, small amounts of arsenic are excreted through other routes (e.g., skin, sweat, hair, breast milk). While arsenic has been detected at low levels in the breast milk of women in northwestern Argentina (i.e., 2 μg/kg), breastfeeding was associated with lower concentrations of arsenic in the urine of newborn children (Concha et al., 1998c) than formula feeding, owing to the use of arsenic contaminated water in formula preparation. Parr et al. (1991) measured arsenic (as well as other elements) in the breast milk from three groups of mothers from four countries (Guatemala, Hungary, Nigeria, and the Philippines), and one to two groups from Sweden and Zaire. The breast milk was collected 3 months after birth. Levels of arsenic in the breast milk from women in the Philippines were higher than other regions with levels about 19 μg/kg. Women from Nigeria had levels similar to those observed by Concha et al. (1998c). Women from all the other areas measured had levels of 0.24 to 0.55 μg/kg.

The average concentration of arsenic in sweat induced in a hot and humid environment was 1.5 μg/L, with an hourly loss rate of 2.1 μg (Vellar, 1969). Based on an average arsenic concentration in the skin of 0.18 mg/kg, Molin and Wester (1976) estimated that the daily loss of arsenic through desquamation was 0.1 to 0.2 μg in males with no known exposure to arsenic.

### D.2.1 Physiologically Based Pharmacokinetic Models

Physiologically based pharmacokinetic (PBPK) models for inorganic arsenic are important for developing a biologically based dose-response (BBDR) model. The development of useful BBDR models has proved to be challenging because inorganic arsenic appears to mediate its toxicity through a range of metabolites, and their roles with regard to specific adverse effects are not clear (Clewell et al., 2007).

A PBPK model for exposure to inorganic arsenic (orally, intravenously, and intratracheally) was developed in hamsters and rabbits by Mann et al. (1996a). The model includes tissue compartments for lung (nasopharynx, tracheobronchial, pulmonary), plasma, RBCs, liver, GI tract, skin, kidney, keratin, and combined other tissues. Oral absorption of As^III^, As^V^, and DMA (pooled III and V oxidation states) was modeled as a first-order transport process directly from the GI contents into the liver. Distribution to tissues was diffusion-limited, with transfer rates estimated based upon literature values for capillary thickness and pore sizes for each tissue. Reductive metabolism of As^V^ to As^III^ was modeled as a first-order process occurring in the plasma. Oxidative metabolism of As^III^ to As^V^ was modeled as first-order processes in the plasma and kidneys. Methylation of inorganic arsenic species to MMA (pooled III and V oxidation states) and then to DMA were modeled as saturable Michaelis-Menten processes taking place in the liver. Urinary, biliary, and fecal excretion of As^III^, As^V^, MMA, and DMA also are modeled as first-order processes. Parameters for absorption, tissue partition, metabolism, and biliary excretion were estimated by fitting the model to literature data on the urinary and fecal excretion of total arsenic from rabbits and hamsters administered various arsenic compounds by iv, oral gavage, or intratracheal instillation (Yamauchi and Yamamura, 1984; Marafante et al., 1985; Marafante et al., 1987; Charbonneau et al., 1980). The model was found to accurately simulate the excretion of arsenic metabolites in the urine of rabbits and hamsters and to produce reasonable fits to liver, kidney, and skin concentrations in rabbits and hamsters (Yamauchi and Yamamura, 1984; Marafante et al., 1985; Marafante and Vahter, 1987).

Mann et al. (1996b) extended their PBPK model for use in humans by adjusting physiological parameters (organ weights, blood flows) and re-estimating absorption and metabolic rate constants. The model was fit to literature data on the urinary excretion of total arsenic following a single oral dose of As^III^ or As^V^ in human volunteers (Tam et al., 1979; Buchet et al., 1981). The extended human model was further tested against empirical data on the urinary excretion of the different metabolites of inorganic arsenic following oral intake of As^III^, intake of inorganic arsenic via drinking water, and occupational exposure to arsenic trioxide (ATO) (Valentine et al., 1979; Vahter et al., 1986; Harrington et al., 1978; Buchet et al., 1981). The model predicted a slight decrease (about 10%) in the percentage of DMA in urine with increasing single-dose exposure (highest dose of arsenic at 15 μg/kg of body weight), especially following exposure to As^III^, and an almost corresponding increase in the percentage of MMA. The model predicted that adults’ drinking water containing 50 ppb would excrete more arsenic in urine than an occupational inhalation exposure of 10 μg/m^3^ (Mann et al., 1996b).

Yu (1999) also developed a PBPK model for arsenic in humans that includes tissue compartments for lung, skin, fat, muscle, combined kidney and richly perfused tissues, liver, intestine, GI and stomach contents, and bile. Oral absorption of As^III^, As^V^, and DMA (pooled III and V oxidation states) was modeled as first-order transport from the GI contents into the intestinal tissue. Distribution to tissues was modeled as perfusion limited. Reductive metabolism of As^V^ to As^III^ was modeled as a first order, GSH-dependent process taking place in the intestinal tissue, skin, liver, and kidney/rich tissues. Oxidative metabolism of As^III^ to As^V^ was not modeled. Methylation of inorganic arsenic species to MMA (pooled III and V oxidation states) and then to DMA was modeled as saturable Michaelis-Menten processes occurring in the liver and kidney. Urinary, biliary, and fecal excretion of As^III^, As^V^, MMA, and DMA were modeled as first-order processes. Parameters for absorption, tissue partition, metabolism, and biliary excretion were estimated by fitting the model to literature data on tissue concentrations of total arsenic from a fatal human poisoning (Saady et al., 1989), and blood, urine, and fecal elimination of total arsenic following oral administration (Pomroy et al., 1980; Odanaka et al., 1980). The model was not tested further against external data, and fits to the data sets used for parameter estimation were not provided.

Gentry et al. (2004) adapted the model proposed by Mann et al. (1996a) to different mouse strains by adjusting physiological parameters (organ weights and perfusion rates). The absorption, partition, and metabolic rate constants were re-estimated by fitting the model to literature data on urinary excretion of various arsenic species following iv administration of MMA to B6C3F1 mice (Hughes and Kenyon, 1998) or single oral administration of As^III^ or As^V^ to mice (Kenyon et al., 1997; Hughes et al., 1999). Additionally, the description of methylation in the model was refined to include the uncompetitive inhibition of the conversion of MMA to DMA by As^III^. The PBPK model was then validated using data from a single oral administration of As^V^ (Hughes et al., 1999) and a 26-week drinking water exposure of As^III^ to C57Black mice (Moser et al., 2000). These data were found to adequately fit the model without further parameter adjustment. Ng et al. (1999) had found arsenic-induced tumors in C57Bl/6J mice, while numerous other mouse strains (Swiss CR:NIH[S], C57Bl/6p53[+/−], C57Bl/6p53[+/+], and Swiss CD-1) had not experienced a significant increase in arsenic-induced tumors. The Gentry et al. (2004) model was unable to explain the different outcomes in the mouse bioassay on the basis of predicted target organ doses.

The Mann et al. (1996a, 1996b) and Gentry et al. (2004) models are well documented, were validated against external data, and appear to capture the salient features of arsenic toxicokinetics in rodents and humans. The information provided by these models may help explain the MOAs involved in carcinogenesis along with possible reasons that humans are apparently more susceptible to the carcinogenic effects of arsenic.

Clewell et al. (2007) noted that the then-available PBPK models did not incorporate the most recent available information on arsenic methylation kinetics and suggested several steps for improving the PBPK models. Kenyon et al. (2008) have developed a PBPK model incorporating some of the improvements suggested by Clewell et al. (2007) (although not the simulation of changes in gene expression). The model predicts the levels of inorganic arsenic and its metabolites in human tissues and urine following oral exposure of As^V^, As^III^, and for oral exposure to organoarsenical pesticides. The model consists of interconnecting submodels for inorganic arsenic (As^III^ and As^V^), MMA^V^, and DMA^V^. Reduction of MMA^V^ and DMA^V^ to their trivalent forms is also modeled. The submodels include the GI tract (lumen and tissue), lung, liver, kidney, muscle, skin, heart, and brain, with reduction of MMA^V^ and DMA^V^ to their trivalent forms modeled as occurring in the lung, liver, and kidney. The model also incorporates the inhibitory effects of As^III^ on the methylation of MMA^III^ to DMA and MMA^III^ on the methylation of As^III^ to MMA into consideration, modeled as noncompetitive inhibition. This model differs from the other models described above because it provides an updated description of metabolism using recent biochemical data on the mechanism of arsenic methylation. In addition, it uses in vitro studies to estimate most of the model parameters (statistically optimizing those that are sensitive to urinary excretion levels to avoid problems with parameter identifiability) and can predict the formation and excretion of trivalent methylated arsenicals. The partition coefficients estimated in the model are comparable to those developed by Yu (1999). The performance of the model was tested against limited human data on urinary excretion; the model needs to be evaluated for its ability to predict the tissue and urinary concentrations of arsenicals in large numbers of subjects. This model is an improvement over previous models because it can quantitatively assess impacts of parameter variability arising from genetic polymorphism.

## D.3 PBPK MODEL EVALUATION SUMMARY

See Section 4 of the Updated Problem Formulation and Protocol for the Inorganic Arsenic IRIS Assessment.

42 Arsenic (+3 oxidative state) methyltransferase (AS3MT) has been referred to by many investigators as cyt19 in their references. According to Thomas et al. (2007), the Human Genome Nomenclature Committee (http://www.gene.ucl.ac.uk/cgi-bin/nomenclature/searchgenes.pl) recommends that this protein be systematically named AS3MT. In this document, references to cyt19 it has been changed to AS3MT to avoid confusion and for uniform consistency.