# APPENDIX C STUDY SELECTION, MODELING METHODS, AND RESULTS FOR DOSE-RESPONSE

## C.1 RISK-AT-A-DOSE BAYESIAN DOSE-RESPONSE META-ANALYSIS

### C.1.1 Bayesian Dose-Response Meta-Analysis Methods

The Bayesian dose-response meta-analysis modeling methods described by Allen et al. (2020b) and Allen et al. (2020a) were used in this assessment. This section summarizes those methods, adding additional details (e.g., for sensitivity analyses) relevant to the specific needs of this assessment. Access to all support files used in the application of these methods is available from the inorganic arsenic HERO project page (https://hero.epa.gov/hero/index.cfm/project/page/project_id/2211).

#### Overall Summary of Hierarchical Bayesian Dose-Response Modeling and Lifetable Methods

A high-level overview of the hierarchical Bayesian dose-response meta-analysis methodology is provided in Figure C-1. Briefly, the overall dose-response analysis workflow can be split into three main domains: 1) pre-analysis consisting of the conversion of study-specific dose metrics into a unified daily intake and estimation of effective counts of cases and controls; 2) Bayesian hierarchical dose-response modeling; and 3) application of lifetable methods to estimate lifetime extra risk of disease.

The conversion of study-specific exposure metrics to a common dose metric is an essential aspect of the iAs dose-response meta-analysis approach as it allows multiple studies to be combined, which increases the precision of the dose-response modeling results. Section C.1.1 (Treatment of Dose Uncertainty) provides additional details on the methods for treating dose uncertainty. Briefly, EPA’s dose conversion approach uses a probabilistic approach wherein the necessary exposure factors necessary to convert study-specific dose metrics into the unified dose-metric (i.e., daily intake in units of µg/kg-day) are applied. These exposure factors (e.g., body weight, water consumption rate, etc.) were assumed to vary within a population and so distributional representation of this variability were applied via Monte Carlo methods to derive posterior distributions of the unified dose-metric. One major benefit of calculating a common dose metric is that the present analysis can include studies that used urinary or toenail biomarkers as the exposure assessment method and studies that assessed exposure since drinking water intake. Application of the empirical relationship between urinary total As concentration and drinking water iAs exposure (as established by the El-Masri-Kenyon PBPK model) to urinary biomarker studies is considered to provide reliable estimates of total arsenic dose and average daily lifetime intake (µg/kg-day) (Allen et al., 2020b; Allen et al., 2020a). Urinary arsenic measurements integrate all sources of oral exposure at the individual level, accounting for arsenic from both water and diet, an important recommendation of NRC (2013), and are a high-quality biomarker of internal dose (NRC, 1999; Marchiset-Ferlay et al., 2012; Hughes, 2006).

To further expand the number of studies that could be included in the iAs dose-response meta-analysis approach, data adjustments were also made to the response measures (i.e., counts of affected and nonaffected individuals) reported in the studies considered for use. These data adjustments result in “effective counts”—non-integer incidence data that consider the controls for confounding that the individual study authors performed, which allows for case-control and cohort studies to be included in the same dose-response meta-analysis. Essentially, effective counts produce the adjusted odds ratio (OR) or relative risk (RR) the study authors report after controlling for confounders. The methods and rationale for deriving effective counts for such study types, described by Allen et al. (2020a) are presented in Section C.1.1 (Adjusting for Covariates). The resulting effective counts for the individual datasets used to model these four endpoints are presented in endpoint-specific modeling results in Section C.1.2.

After generating the modeling inputs (i.e., study-specific daily intake values and effective counts) in the pre-analysis step, dose-response meta-analyses for bladder cancer, lung cancer, IHD and diabetes were conducted using Bayesian-derived methods (see Section C.1.1: Bayesian Dose-Response Meta-Analysis Methods). A logistic-power model was used because they allow for a unified, consistent analysis of both case-control and cohort studies together in a single dose-response meta-analysis (Allen et al., 2020b; Allen et al., 2020a). As Allen et al. (2020b) describes the hierarchical structure for the dose-response meta-analysis assumes the α* parameter was separate and independent for each data set. Study-specific β values that were normally distributed around a mean (β_mean) with some standard deviation (β_sigma) were assumed. Both β_mean and β_sigma are estimated from the study-specific values. The parameter β_mean, in particular, is the parameter representing the “pooled” or “average” coefficient for arsenic dose that is a critical parameter in the extrapolation stage, where target-population risks are estimated. Additionally, the estimated power parameter (on the dose term; q) is not hierarchical and the estimated value applied to both study-specific and pooled analyses. Prior probability distributions were assigned to the model parameters as shown in Table C-1 and the overall hierarchical structure of the model is provided in Figure C-1.

Table C-1 Prior parameter values for dose-response meta-analyses

Parameter | Prior distribution
β(i)^a^ | Normal (β_mean, β_sigma)
β_mean | Gamma (a = 0.52, b = 1.12)
β_sigma | Half − Cauchy (scale = 5, location = 0)
power (q) | Half − Cauchy (scale = 0.315, location = 1)

a β(i) is the dose coefficient for data set i.

Figure C-1 Hierarchical structure of Bayesian dose-response meta-analysis model

Note: dark blue boxes represent parameter prior distributions, orange boxes represent unknown parameters, and green boxes represent prior distributions for hierarchical parameters. Parameters in orange boxes are updated via Markov Chain Monte Carlo (MCMC) simulation.

The gamma prior for β_mean reflects the determination that arsenic is causal for the health outcomes analyzed so that its coefficient in the model should not be negative.^1^ The specific choices for the values of the “a” and “b” parameters that define a Gamma distribution are discussed in Allen et al. (2020b) and reflect the judgment that a relatively diffuse, uninformative prior should be used for the Bayesian modeling to represent the prior probability of both weak and strong associations between arsenic exposure and bladder cancer incidence. To represent this diffuse prior, a gamma distribution was selected such that the OR would be unlikely to be greater than 20 at a dose of 1 μg/kg (p < 0.01) and equally unlikely to be less than 1.0001 at that dose.^2^ A prior for α*(i) is not needed; it is a function of β(i) and either the expected number in the referent group (for a cohort study) or the proportions of controls in the exposure groups (for a case-control study). The key output of the dose-response meta-analyses is the posterior distribution for the “pooled” (average) value of the logistic slope.

The last step in the dose-response workflow is to take the posterior distribution of the pooled logistic slope and use it in a lifetable analysis to estimate the U.S. population lifetime^3^ probability of observing a health outcome as a function of iAs dose (average μg/kg-day). The overall methodology is described by Allen et al. (2020b) and Allen et al. (2020a). Details of the lifetable calculations vary by health outcome and are discussed separately in the individual health outcome sections (see Sections 4.3.5 through 4.3.8). An important aspect of all the lifetable applications, however, is that the exposure scenario used posits a continuous, full lifetime exposure to a constant iAs dose, which includes a background U.S. iAs dose that is associated with the background U.S. risks estimated by the lifetables. For each health outcome analyzed in Sections 4.3.5 through 4.3.8, the focus is on describing the relationship between U.S. lifetime extra risk above an estimate of the U.S. risk at a zero iAs dose and a full lifetime exposure to some assumed constant iAs dose. Estimates for U.S. lifetime background risks of 1.9% for bladder cancer and 5.7% for lung cancer (see Section 4.3.4) were obtained from CDC lifetables. U.S. lifetime risks of 40% for IHD (Lloyd-Jones et al., 1999)^4^ and 40% for diabetes (Gregg et al., 2014) were approximated from published rates due to the lack of lifetable data. The zero-dose U.S. lifetime risks were obtained by extrapolation, using the logistic slope estimates obtained from the dose-response meta-analysis and assuming that the U.S. lifetime background risks are associated with a background dose of 0.0365 µg iAs/kg-day, 0.02 µg iAs/kg-day from dietary food consumption and 0.0165 µg iAs/kg-day from drinking water.^5^ The El-Masri-Kenyon iAs PBPK model indicates this level of U.S. background intake is consistent with the estimated 1–5 μg/L urinary background levels of total arsenic (summing inorganic, monomethyl, and dimethyl arsenic forms) that NRC (2013) considered to a reasonable for the U.S. population.

#### Treatment of Dose Uncertainty

The treatment of dose estimation and conversion to a common set of units has been handled as summarized in Figure C-2.

Figure C-2 Dose uncertainty flow chart in relation to MLE, low-end, and high-end dose sets and risk estimates

^1^High group means minimized or maximized subject to constraint that −2*(LL–MLL) < 2.706 (a 95% bound on the high-group mean). LL is the log-likelihood for the lognormal distribution for the candidate parameter vector; MLL is the maximum log-likelihood. When a published study reports the mean or median values for each group, those values are used directly as the group-specific dose values, with no lognormal fitting.

^2^The terminology “low-end,” “high-end,” and MLE estimates are used to avoid confusing the values with credible (or confidence) interval bounds having a specific numerical value (e.g., 95%). Combining the log-likelihood bounds for group-specific means, with percentiles from the Monte Carlo analysis, and with percentiles of the β_mean distributions does not allow determination that the bounding estimates have any identifiable associated “confidence level.” They do, however, produce reasonable semi-quantitative limits on how uncertain the resulting estimates are.

##### Estimating representative values for exposure groups

When the published reports of a study present results categorized by exposure group, and those groups are defined in terms of ranges of exposure without providing mean or median values for each group,^6^ EPA had to estimate those means to serve as the “representative” values for the exposure groups. In essence, EPA treated the data as if the observations within a group had the same (mean) value estimated for that group. The procedure for doing that is described here.

Suppose that a study has G exposure groups defined as (c_0_, c_1_),(c_1_, c_2_), … , (c_G−1_, c_G_); c_0_ may equal 0 and c_G_ may equal ∞. Let τ, with elements τ_g_, be the vector of observed proportions of individuals in groups g = 1, …, G. As discussed below, for a case-control study, only the control counts were used to define the τ values; otherwise, all individuals were used to define τ.

EPA assumes that individual exposures follow a lognormal distribution with parameters μ and σ (respectively, the mean and standard deviation of natural logarithms of exposure); the same assumption was made by Moon et al. (2017) in their analysis of arsenic risks. EPA estimates these parameters by maximum likelihood (ML), maximizing the following log-likelihood expression appropriate for the censored data:

log − l i k e l i h o o d = N ⋅ Σ_g = 1_^G^ τ_g_ ⋅ ln ( φ ( ln ( c_g_ ) | μ , σ ) − φ ( ln ( c_g − 1_ ) | μ , σ ) ) (C-1)

where N is the total number of observations under consideration and φ(x | μ, σ) is the cumulative distribution function for the Normal distribution with mean μ and standard deviation σ. Let μ’ and σ’ be the ML estimates (MLEs) given τ and the values of c_g_ (g = 0, …, G). A simple likelihood maximization routine, implemented with an Excel spreadsheet (see Supplemental Material), was used to estimate μ’ and σ’.

Given μ’ and σ’, the mean within a given exposure interval (c_g_, c_g+1_) is given by:

m e a n ( g ) = e^( μ ' + (σ '^2^)/(2) )^ × (θ ( U_1_ ( g ) − σ ' ) − θ ( U_0_ ( g ) − σ ' ))/(θ ( U_1_ ( g ) ) − θ ( U_0_ ( g ) )) , (C-2)

where U_1_ ( g ) = (( I n ( c_g + 1_ ) − μ^′^ ))/(σ^′^) , U_0_ ( g ) = (( I n ( c_g_ ) − μ^′^ ))/(σ^′^) , and θ() is the cumulative distribution function for the standard normal distribution (Söderlind, 2013).

In addition to the maximum likelihood estimate of an exposure for each dose group, EPA has computed what are referred to as “low-end” and “high-end” exposure estimates. Those estimates were based on profile likelihood bounds for the mean exposure for individuals in the high-exposure group. First, EPA computed the maximized log-likelihood (MLL) (the log-likelihood associated with MLEs of the parameters μ and σ). Then the mean value for the high group was maximized by modifying μ and σ subject to the constraint that:

− 2 × ( L L − M L L ) ≤ 2.706 (C-3)

where LL is the log-likelihood associated with the modified μ and σ. This is a chi-squared-based (1 degree of freedom) 95% confidence upper bound on the high-group mean. The same procedure was followed to determine a 95% confidence lower bound on the high group mean by minimizing the mean value for the high group under the same constraint (Eq C-2).

Note that we are only specifically maximizing (or minimizing) the mean for the highest exposure group. In some instances, this may result in a change in the estimated mean for other groups (primarily the lowest exposure group) when the modified μ and σ are input into Eq C-1. EPA has opted for this procedure for two primary reasons. First, the highest exposure group is almost always the one that is most uncertain, often presented as an open-ended interval. The mean for that group is not easily nor consistently estimated by techniques that can be applied to the other exposure groups (e.g., by taking the midpoint of the interval). Second, the dose and response observations for the highest exposure group often have a large impact on dose-response model estimation. Especially for the slope parameters in a model, the positioning of the highest dose-response pair can be very influential. Thus, our procedure focuses on that influential observation and derives bounds specifically tailored to determine the full range of possible values for exposure consistent with the data (and our assumption of lognormality of exposures over the studied population) for that observation.

##### Unit conversion uncertainties

Estimation of a common dose metric (as opposed to exposure metric)^7^ for all studies is imperative to account for the effect of dose on the estimated response. However, epidemiologic studies often use different, but related, exposure- or dose-metrics such as exposure concentration, cumulative exposure, and even biomarkers of exposure such as internal tissue concentrations or urinary concentrations of the chemical of interest. In this specific case-report, if the data presented in all the published studies had been in the units of interest (daily average μg/kg-day), no conversion would be necessary, and dose-response meta-analysis (DRMA) could be performed with the study-reported data. However, that was not the case for the studies under consideration here, nor would it be in general practice. Furthermore, epidemiological risk assessments do not always include results from regression analysis, the type of data that directly accounts for inter-individual variability. Considering a recent call from the NAS to better account for uncertainty in the dose-response approach, EPA views this as a major shortcoming.

To address these issues, the proposed DRMA includes a dose conversion step that converts disparate exposure or dose metrics into a common dose metric while accounting for uncertainty. The dose conversion is performed at the dose group level. A common dose metric is calculated for each dose group from a set of conversion factors. Conversion factors are typically approximated by population-level sample means in the inorganic arsenic (iAs) literature; dose-group-level data is not often available. However, using population-level means for a group-level analysis ignores sampling variability that would likely exist between group-level means. It also ignores the fact that groups with more observations have less uncertain mean estimates than those with fewer observations. Neglecting to account for these sources of variation impacts the final common dose metric estimate by biasing our estimate away from the null. Accordingly, we include a Monte Carlo (MC) sampling step in our dose conversion process to explicitly consider exposure group sample sizes in the mean estimates of conversion factors.

Our approach allows for the use of multiple exposure metrics to characterize iAs exposure and answers the NAS call to address uncertainty. This approach is designed to accommodate the unique features of the iAs literature (e.g., many studies with large variation in exposure metrics and with results reported as exposure ranges with associated adjusted RRs or ORs with confidence intervals) and is not necessarily intended to be generalized to other approaches. It is worth noting that if group-level summary statistics are in fact reported, EPA recommends proceeding with the dose conversion without the MC sampling step.

###### Dose-conversion method overview

The first step in our dose conversion approach is to identify the factors required to convert to μg/kg-day. As an example, consider a study that reported cumulative drinking water exposures, in (μg iAs/L drinking water) × years. The conversion from cumulative exposures to average daily dose (μg/kg–day) was carried out as follows:

intake = D I + f ( (C E × W C R)/(R D W E) ) + ( 1 − f ) ( L E × W C R ) (C-4)

where the terms in that expression are DI = dietary intake (average daily μg/kg − day); f = fraction of time (over lifetime up through the study) spent consuming well water (unitless); WCR = water consumption rate (L/kg − day); CE = cumulative iAs exposure ( (μ g)/(L) * year); and LE = low-end water concentration (μg/L). The variable f was calculated as the ratio of the assumed average duration of well exposure (ADWE), generally the reported duration of drinking well water (RDWE; yr), to the average age at diagnosis (AAD; yr). It was assumed that when drinking non-well water, the subjects consumed water with the low-end water concentration. The values used in Eq C-4, above ideally would come from study-specific data reported in the study of interest but could also be drawn from other suitable sources (e.g., from other studies reporting on the same study population or from national authoritative sources). See Table C-2 below for a full list of conversion equations.

Table C-2 Conversion equations to convert study-specific exposure metrics into unified daily intake metric

Cumulative lifetime drinking water intake (mg)
i n t a k e ( (μ g)/(k g) − d a y ) = D I ( (μ g)/(k g) − d a y ) + f ( ((C E ( μ g ))/(A g e ( y r ) × 365))/(B W ( k g )) ) + ( 1 − f ) ( L E ( (μ g)/(L) ) × W C R ( (L)/(k g) − d a y ) ) Equation A
Cumulative daily drinking water exposure (mg/day)
i n t a k e ( (μ g)/(k g) − d a y ) = D I ( (μ g)/(k g) − d a y ) + f ( (C E ( (μ g)/(d a y) ))/(B W ( k g )) ) + ( 1 − f ) × ( L E ( (μ g)/(L) ) × W C R ( (L)/(k g) − d a y ) ) Equation B; or; i n t a k e ( (μ g)/(k g) − d a y ) = D I ( (μ g)/(k g) − d a y ) + f ( (C E ( (μ g)/(d a y) ))/(B W ( k g )) ) + ( 1 − f ) × ( (( L E ( (μ g)/(L) ) × W C R ( (L)/(d a y) ) ))/(B W ( k g )) ) Equation C
Drinking water concentrations (mg/L)
i ntake ( (μ g)/(k g) − d a y ) = D I ( (μ g)/(k g) − d a y ) + f ( W E ( (μ g)/(L) ) × W C R ( (L)/(k g) − d a y ) ) + ( 1 − f ) ( L E ( (μ g)/(L) ) × W C R ( (L)/(k g) − d a y ) ) Equation D
Cumulative exposure ( (μ g)/(L) * y e a r s )
intake ( (μ g)/(k g) − d a y ) = D I ( (μ g)/(k g) − d a y ) + f ( (C E ( (μ g)/(L) − y r ) × W C R ( (L)/(k g) − d a y ))/(R D W E ( y r )) ) + ( 1 − f ) ( L E ( (μ g)/(L) ) × W C R ( (L)/(k g) − d a y ) ) Equation E
Urinary concentration^a^ ( (μ g A s)/(g C r e a t i n i n e) )
intake ( (μ g)/(k g) − d a y ) = (U r i n a r y A s ( (μ g A s)/(g C r e a t i n i n e) ) × C r e a t i n i n e ( (g)/(d a y) ))/(B W ( k g )) Equation F; C r e a t i n i n e ( (g)/(d a y) ) = ( 266.16 − ( 47.17 × S e x ( 0 , 1 ) ) − ( 2.33 × B M I ) + ( 0.66 × A g e ) + ( 0.017 × A g e^2^ ) ) + (113.2)/(10^6^) × B W Equation G
Toenail concentration ( (μ g A s)/(g t o e n a i l) )
I f t o e n a i l A s < 0.028 (μ g A s)/(g t o e n a i l) , d r i n k i n g w a t e r ( (μ g)/(L) ) = 10^− 0.4 + 0.1 × log_10_ ( t o e n a i l c o n c e n t r a t i o n (μ g A s)/(g t o e n a i l)^ Equation H; I f t o e n a i l A s > 0.028 (μ g A s)/(g t o e n a i l) , d r i n k i n g w a t e r ( (μ g)/(L) ) = 10^1.4 + 0.9 × log_10_ ( t o e n a i l c o n c e n t r a t i o n (μ g A s)/(g t o e n a i l)^ Equation I

CE = cumulative exposure; DI = dietary intake; LE = low exposure level; WCR = water consumption rate; BW = body weight; RDWE = reported duration of exposure.

a According to the El-Masri-Kenyon PBPK model (El-Masri et al., 2018a, b), iAs is eliminated almost exclusively in urine. Thus, total µg/kg-day arsenic in urine is a good approximation of µg iAs/kg-day intake, assuming arsenic intake is substantially in the form of iAs. Urinary creatinine/kg-day is estimated as = (266.16–47.17*sex–2.33*BMI + 0.66*age + 0.17*age^2^)*113.12/10^6^, where sex is 0 for male and 1 for female and BMI is estimated as BW/(Height/100)^2^.

Next, probability distributions are inferred for each conversion factor with parameters based on the factor’s reported means and standard deviations. The distribution assumed for the individual conversion factors is either based on sources from the scientific literature or assumptions given the nature of the conversion factor (e.g., using a lognormal distribution for non-negative data). For instance, lognormal distributions were assumed for DI, WCR, RDWE, and LE, whereas a beta distribution was used for the f variable. These distributions represent individual or population-level variability in each factor and were based on knowledge of the population from which the study participants were drawn (e.g., exposure factors handbook values or study-specific data). Independence between the conversion factors is assumed.

We then conduct an MC analysis, sampling from the assumed distributions for the exposures within a group and for each exposure factor. For a given study, the respective distributions for the conversion factors are sampled N times, where N is the number of individuals in a dose group, and computed N daily intake values (representing the N individuals in the group). In situations where N > 1,000, the analysis is truncated at 1,000 to ease computational burden, as distributions of mean values with this many random values can be expected to be narrow. EPA averaged across the resulting N individual daily intake values to generate a final, average daily intake value for each dose group. This process was repeated 1,000 times to derive a MC distribution of average daily intake values. The overall median as well as the 5th and 95th percentiles of the sample means were calculated from the MC simulation results to characterize the MLE, low-end, and high-end dose values. The entire procedure is implemented using the Excel add-in, YASAIw v2.0. When necessary, reported summary statistics were converted to the appropriate scale or value to be used as distribution parameters either via YASAI or by hand. For full details of the analysis, see Allen et al. (2020a).

Other items to note include the fact that dietary exposure is included in all the conversions. Thus, our dose estimates represent total iAs daily intake from all oral routes, not necessarily just exposure from drinking water. Our approach explicitly considers the sample sizes in each exposure group; by averaging over the number of individuals in each group, it is automatically considered that groups with more observations will be less uncertain (about the mean group-specific conversions) than groups with fewer observations.

Finally, note that each study, possibly reporting different exposure summaries, is handled differently depending on the reported units. For example, consider a study that used daily arsenic exposure (in units of µg/day) as the dose metric rather than cumulative exposure in units of (μg iAs/L drinking water) * years. Thus, the conversion to average daily μg/kg–day (dose) was carried out as follows:

d o s e = D I + f × ( (C E)/(B W) ) + ( 1 − f ) × ( W C R × L E ) (C-5)

where the terms in that expression are as above, except that CE now corresponds to cumulative daily dose (µg/day) and the variable BW = body weight (kg) is used.

All dose conversions were computed via Excel, using the MC simulation add-in Yasai (www.yasai.rutgers.edu). While other software programs or languages (i.e., R or Python) are more powerful in some regards and could be used to implement the dose-conversions, Excel was chosen for its ubiquity of use and because Excel workbooks are useful for organizing the analyses for presentation.

Note that for studies that characterized exposure to inorganic As via measurement of urinary total As, the empirical relationship between urinary tAs concentration and drinking water concentration was used to perform dose-conversions; the PBPK model was not run individually on study-specific exposure metrics in order to do the conversions. According to the El-Masri-Kenyon PBPK model (El-Masri and Kenyon, 2008), iAs is eliminated almost exclusively in urine. Thus, total µg/kg-day arsenic in urine is a good approximation of μg iAs/kg-day daily intake, assuming arsenic daily intake is substantially in the form of iAs. To obtain estimates of µg iAs/kg-day daily intake, EPA multiplies µg total As/g creatinine (units reported in most studies) by an estimate of g creatinine/kg-day. Urinary creatinine/kg-day is estimated as = (266.16–47.17 × sex−2.33 × BMI + 0.66 × age + 0.17 × age^2^) × 113.12/10^6^, where sex is 0 for male and 1 for female and BMI is estimated as BW/(height/100)^2^.

###### Details on dose conversion method development, including sensitivity analyses

This section contains a discussion and sensitivity analyses which address the following key issues: distributional assumptions for conversion factors and sensitivity of the conversions to reported conversion factor sample means.

###### Random sampling of exposure metrics

In addition to assuming that all conversion factors follow a probability distribution, the dose conversion methodology also involves random sampling from the distribution of exposure metric values. Our approach utilizes a restricted lognormal distribution where the limits of sampling correspond to the minimum and maximum of each dose metric range and that samples proportionately to the number of individuals observed in each dose range. EPA implemented this approach using inverse probability sampling.

Although including sampling from the exposure metric distribution for the dose conversion method is conceptually more robust than relying on a single dose metric estimate, it does not result in a large difference in the ultimate daily intake estimated via Monte Carlo sampling. This difference is illustrated by comparing dose metric estimates calculated via the sampling approach to dose metric estimates calculated using single point exposure estimates calculated via maximum likelihood estimation (MLE) for the Meliker et al. (2010) and Chen et al. (2010b) study (see Table C-3). Results show that when considering the low dose group, the final “Most Likely (Mean)” daily intake changed 0.0% when comparing the MLE approach to the sampling methodology for the Meliker et al. (2010) study. See “LOGNORMAL” vs. “ORIGINAL” results in the Main tab of the Meliker2010_CE5-Ln_ugperday-08-08-22-sensitivity analysis.xlsx located in the bladder cancer intake uncertainty folder of the arsenic dose-response supplemental files (U.S. EPA, 2025), which are accompanied by an explanatory structured workflow, outline, and variable dictionary (U.S. EPA, 2024b). The magnitude of difference is larger when comparing the high dose group for “Low (5th percentile)” and “High (95th percentile) estimates of daily intake: 13.5% (from 0.334 to 0.379) and −23.1% (from 0.723 to 0.556), for the low and high estimates, respectively. This is consistent with the fact that daily intake estimates reflect sampling in the tails of the distribution (with the larger difference in the high (95th percentile) daily intake value explained by the right skewedness of the lognormal distribution). The effect on final daily intake values is of a smaller magnitude in the Chen et al. (2010b) study, with the low dose “Most Likely (Mean)” changing 0.0% and the high dose group differences being <10% consistent with the larger sample size in that study. See “LOGNORMAL” vs. “ORIGINAL” results in the Main tab of the Chen_2010_NE_Taiwan_bladder-08-10-22-sensitivity analysis.xlsx located in the bladder cancer intake uncertainty folder of the arsenic dose-response supplemental files (U.S. EPA, 2025), which are accompanied by an explanatory structured workflow, outline, and variable dictionary (U.S. EPA, 2024b).

Table C-3 Fixed dose metrics versus sampled (random) dose metrics

Dose ranges | Most likely (Mean) | | Low (5th percentile) | | High (95th percentile)
Dose ranges | Random^a^ | Fixed^b^ | Random^a^ | Fixed^b^ | Random^a^ | Fixed^b^
Meliker et al. (2010)
0–10 | 0.103 | 0.103; (0.0%) | 0.097 | 0.096; (−0.6%) | 0.110 | 0.110; (0.8%)
10–100 | 0.145 | 0.139; (−4.1%) | 0.136 | 0.130; (−3.9%) | 0.154 | 0.148; (−4.3%)
100–1,000 | 0.455 | 0.454; (−0.3%) | 0.334 | 0.379; (13.5%) | 0.723 | 0.556; (−23.1%)
Chen et al. (2010b)
0–400 | 0.830 | 0.830; (0.0%) | 0.810 | 0.810; (0.0%) | 0.851 | 0.853; (0.1%)
400–1,000 | 1.106 | 1.108; (0.1%) | 1.078 | 1.080; (0.2%) | 1.136 | 1.135; (−0.1%)
1,000–5,000 | 2.042 | 2.039; (−0.1%) | 1.956 | 1.971; (0.8%) | 2.120 | 2.109; (−0.5%)
5,000–10,000 | 4.65 | 4.64; (−0.2%) | 4.40 | 4.40; (0.0%) | 4.91 | 4.89; (−0.4%)
10,000–100,0000 | 21.60 | 21.72; (0.6%) | 18.20 | 19.65; (8.0%) | 26.15 | 24.02; (−8.1%)

a Random = MC sampling from lognormal distribution.

b Fixed = original.

###### Distributional assumptions for conversion factors

The dose-conversion approach assumes that conversion factors can be described via probability distributions. Details and justifications for all conversion factors used in the EPA dose-response meta-analyses are documented in the “conversion actor validation spreadsheet” available in the arsenic dose-response supplemental files (U.S. EPA, 2025), which are accompanied by an explanatory structured workflow, outline, and variable dictionary (U.S. EPA, 2024b). This section provides a summary of the choice of distributions used for the individual conversion factors. As Table C-4 summarizes, distributional assumptions stem from the literature where possible, and otherwise, were chosen so as to reflect the most appropriate distribution given the type of data.

The distributions of body weight, low exposure concentration, U.S. water consumption rate (WCR) and dietary intake, can all be justified in the literature. Distributions for the conversion factors, f-value, WCR outside the U.S. and reported duration of well-exposure (RDWE), were not available in the literature and so were chosen based on the data types and expert judgement. The f-value is bounded between 0 and 1 and has a “most-likely value,” namely the quotient of average values of age and duration of exposure. The f-value is defined as the ratio between average age at diagnosis and the reported duration of well exposure. Hence, EPA used the PERT-beta distribution, which is appropriate for bounded data with known “most-likely” value. Since WCR and RDWE are always greater than or equal to zero, and range from zero to infinity (theoretically), EPA chose a lognormal distribution as representative, since it is restricted to non-negative values (see Table C-4 below). For U.S. studies like Meliker et al. (2010) that did not provide an indication of study-specific WCR, mL/kg-day 16.6 (SE, 0.3) mL/kg-day SE reported for 65% of the sampled U.S. population (15,219) in Table 3-21 of the EPA Exposure Factors Handbook (U.S. EPA, 2019). Note: updated dose-conversion workbooks for U.S. populations used a value of 10.7 mL/kg-day for the water consumption rate, reported for all consumers in Table 3-12 of the Exposure Factors Handbook (U.S. EPA, 2019).

Table C-4 Conversion factor probability distributions

Conversion factor | Distribution | Rationale and citation
Body weight | Lognormal | The lognormal distribution is reported to fit the percentiles for weight for men and women as a function of age (from 6 mo to 74 yr (Burmaster and Crouch, 1997; Brainard and Burmaster, 1992).
Low exposure concentration | Lognormal | The lognormal distribution is reported to provide best fit to drinking water concentrations; EPA assumed this is true for low exposure drinking concentrations as well (Xue et al., 2010)^a^.
Dietary intake | Limited Normal | The technical manual for SHEDS-Dietary model that Xue et al. (2010) used to estimate dietary intake indicates that a normal distribution was used for consumption. The MCMC simulation limited dietary contribution to between 0 and 1,000 µg/kg-d.
f-Value (ratio of assumed avg. duration of well exposure to average age at diagnosis) | PERT-Beta | The PERT-Beta distribution is appropriate for bounded data with known “most likely value” (YASAI-W User Manual). The f-value is bounded by the interval 0–1 given it is a ratio of the duration of well exposure to average age at diagnosis, with a “most likely value” being the ratio of the average values for both of those variables.
Water consumption rate | Lognormal | The lognormal distribution appropriately represents nonnegative data, such as the water consumption rate. To reflect the data reported in U.S. EPA (2019), the MCMC WCR distribution for U.S. studies (lacking study-specific information) simulate a lognormal distribution with a mean of 16.6 µL/kg-d and SD of 37 (0.3 SE × √15,219), adjusting values to zero with a 35% probability.
Reported duration of well exposure | Lognormal | The lognormal distribution appropriately represents nonnegative data, such as reported duration of well exposure.

a This additionally provides justification for choosing a lognormal distribution for all dose metrics (see Topic #1, above) as all dose metrics are ultimately derived from drinking water concentrations.

EPA also considered restricted normal and uniform distributions but found no substantial difference between the resulting daily dose estimates and those from an analysis using lognormal distributions for WCR and RDWE (see Table C-5). For example, for the Meliker et al. (2010) study, when assuming a lognormal distribution for both WCR and RDWE, the MLE low dose daily intake estimate is 0.103 µg/kg-day; changing the assumption to either a restricted normal or uniform distribution for both variables only changes the final daily intake MLE value 6% (0.109 µg/kg-day) and 3% (0.106 µg/kg-day), respectively. The magnitude of difference is similar for other MLE, low (5th percentile) and high (95th percentile) dose estimates for Meliker et al. (2010) and Chen et al. (2010b), particularly low- to mid-exposure levels. Hence, EPA concludes that our results are robust to the choice lognormal, restricted normal and uniform distributions, and makes the conceptually appropriate and computationally efficient assumption that WCR and RDWE follow a lognormal distribution.

Table C-5 MLE, low and high MCMC dose estimates for three different WCR and RDWE distribution assumptions

Exposure ranges (µg/L) | Most likely (MLE; µg/kg-d) | | | Low (5th percentile µg/kg-d) | | | High (95th percentile µg/kg-d)
Exposure ranges (µg/L) | Log-normal | Normal | Uniform | Log-normal | Normal | Uniform | Log-normal | Normal | Uniform
Meliker et al. (2010)
0–10 | 0.103 | 0.109 | 0.106 | 0.097 | 0.101 | 0.099 | 0.110 | 0.116 | 0.112
10–100 | 0.145 | 0.145 | 0.152 | 0.136 | 0.136 | 0.142 | 0.154 | 0.154 | 0.162
100–1,000 | 0.455 | 0.450 | 0.457 | 0.334 | 0.333 | 0.336 | 0.723 | 0.729 | 0.706
Chen et al. (2010b)
0–400 | 0.830 | 0.835 | 0.771 | 0.810 | 0.804 | 0.753 | 0.851 | 0.897 | 0.788
400–1,000 | 1.106 | 1.275 | 0.928 | 1.078 | 1.013 | 0.908 | 1.136 | 1.325 | 0.949
1,000–500 | 2.042 | 2.463 | 1.460 | 1.956 | 1.800 | 1.418 | 2.120 | 2.753 | 1.503
5,000–10,000 | 4.646 | 13.561 | 2.942 | 4.402 | 3.551 | 2.820 | 4.912 | 6.973 | 3.072
10,000–100,000 | 21.595 | 22.264 | 12.685 | 18.196 | 15.074 | 10.634 | 26.152 | 37.053 | 15.284

To define the assumed distributions of the conversion factors, mean and standard deviations identified in the literature are used. While these mean and standard deviation values are from reliable sources (i.e., peer-reviewed articles, authoritative exposure factor documents, etc.), it is possible that error is introduced into the final daily intake values if the reported means do not accurately reflect the true population mean. A sensitivity analysis was conducted to address this.

For two representative studies, Meliker et al. (2010) and Chen et al. (2010b), EPA added/subtracted 5% and 10% to each conversion factor mean. Five and ten percent were chosen to simulate varying amounts of measurement error. The altered means were then used as centrality parameters to define the conversion factor sampling distributions, which were used to carry out the sampling approach to get estimates of the most likely, low, and high lifetime daily dose. Finally, EPA compared these estimates to those from an analysis with the default, unchanged means in order to evaluate the robustness of the lifetime daily dose estimates to variation in the conversion factor means (see Table C-6).

Consistent, but small, generally <10%, changes in each estimate were found for the analyses with 5% and 10% added/subtracted. Table C-6 summarizes the results from the analysis with 5% and 10% added/subtracted. For details, see “LOGN” results, Main tab, Meliker2010_CE5-Ln_ugperday-08-08-22-sensitivity analysis.xlsx and Chen_2010_NE_Taiwan_bladder-08-10-22-sensitivity analysis.xlsx in the bladder cancer intake uncertainty folder of the arsenic dose-response supplemental files (U.S. EPA, 2025), which are accompanied by an explanatory structured workflow, outline, and variable dictionary (U.S. EPA, 2024b). Therefore, EPA concludes that the analysis is tolerably insensitive to changes in the mean values of the exposure factors used to inform the distributions of the conversion factors.

Table C-6 Sensitivity of MC sampling to variation in conversion factor means; dose estimates and percent change

Dose range | Most likely (Mean; µg/kg-d) | | | | | Low (5th percentile; µg/kg-d) | | | | | High (95th percentile; µg/kg-d)
Dose range | 0% | −5% | 5% | −10% | 10% | 0% | −5% | 5% | −10% | 10% | 0% | −5% | 5% | −10% | 10%
Meliker et al. (2010)
0–10 | 0.103 | 0.102 | 0.105 | 0.101 | 0.107 | 0.097 | 0.095 | 0.098 | 0.094 | 0.100 | 0.110 | 0.108 | 0.112 | 0.108 | 0.114
0–10 | 0.103 | −1.1% | 1.8% | −2.0% | 3.7% | 0.097 | −1.6% | 1.1% | −2.9% | 3.5% | 0.110 | −1.1% | 1.9% | −1.8% | 3.7%
10–100 | 0.145 | 0.141 | 0.148 | 0.138 | 0.153 | 0.136 | 0.133 | 0.139 | 0.129 | 0.143 | 0.154 | 0.150 | 0.159 | 0.147 | 0.162
10–100 | 0.145 | −2.6% | 2.4% | −4.9% | 5.8% | 0.136 | −2.3% | 2.9% | −5.0% | 5.6% | 0.154 | −3.1% | 2.6% | −4.7% | 5.2%
100–1,000 | 0.455 | 0.422 | 0.474 | 0.393 | 0.497 | 0.334 | 0.315 | 0.345 | 0.294 | 0.362 | 0.723 | 0.659 | 0.752 | 0.610 | 0.746
100–1,000 | 0.455 | −7.4% | 4.0% | −13.7% | 9.1% | 0.334 | −5.6% | 3.4% | −11.9% | 8.4% | 0.723 | −8.9% | 4.0% | −15.7% | 3.2%
Chen et al. (2010b)
0–400 | 0.830 | 0.796 | 0.865 | 0.764 | 0.899 | 0.810 | 0.776 | 0.845 | 0.743 | 0.878 | | 0.819 | 0.888 | 0.787 | 0.920
0–400 | 0.830 | −4.1% | 4.2% | −8.0% | 8.3% | 0.810 | −4.3% | 4.3% | −8.3% | 8.4% | | −3.8% | 4.2% | −7.6% | 8.1%
400–1,000 | 1.106 | 1.068 | 1.148 | 1.026 | 1.190 | 1.078 | 1.039 | 1.122 | 0.996 | 1.163 | | 1.097 | 1.122 | 1.056 | 1.218
400–1,000 | 1.106 | −3.5% | 3.8% | −7.3% | 7.5% | 1.078 | −3.6% | 4.1% | −7.5% | 7.9% | | −3.5% | 3.8% | −7.0% | 7.2%
1,000–5,000 | 2.042 | 1.976 | 2.105 | 1.915 | 2.172 | 1.956 | 1.893 | 2.031 | 1.832 | 2.091 | | 2.058 | 2.031 | 1.998 | 2.252
1,000–5,000 | 2.042 | −3.2% | 3.1% | −6.2% | 6.4% | 1.956 | −3.2% | 3.8% | −6.4% | 6.9% | | −2.9% | 3.1% | −5.7% | 6.2%
5,000–10,000 | 4.65 | 4.52 | 4.77 | 4.39 | 4.91 | 4.40 | 4.26 | 4.51 | 4.11 | 4.67 | | 4.81 | 4.51 | 4.67 | 5.17
5,000–10,000 | 4.65 | −2.8% | 2.7% | −5.5% | 5.6% | 4.40 | −3.2% | 2.5% | −6.7% | 6.0% | | −2.2% | 2.6% | −4.9% | 5.1%
10,000–1,000,000 | 21.60 | 21.21 | 22.29 | 20.65 | 22.85 | 18.20 | 17.48 | 18.65 | 17.12 | 19.06 | | 25.87 | 18.65 | 25.46 | 27.45
10,000–1,000,000 | 21.60 | −1.8% | 3.2% | −4.4% | 5.8% | 18.20 | −3.9% | 2.5% | −5.9% | 4.7% | | −1.1% | 2.7% | −2.7% | 5.0%

The most likely low and high lifetime daily dose was estimated for both Meliker et al. (2010) and Chen et al. (2010b) using analyses with no change (0%), 5% and 10% subtracted from, and 5% and 10% added to each conversion factor mean. Since BW has an inverse effect, the opposite was applied.

Units = µg/kg-day; values in parentheses represent magnitude of percent change between original values and ± 5% or ± 10% values.

#### Adjusting for Covariates

##### Computation of effective counts for Bayesian dose-response meta-analyses

For both cohort and case-control studies, published manuscripts almost always report adjusted relative risks (RR’s) or odds ratios (OR’s), respectively. The adjusted results attempt to factor out the effects of other, possibly confounding, variables, in order to estimate the effect specifically associated with the exposure of interest, in this case arsenic exposure.

The Bayesian approach that EPA has adopted for the dose-response analysis (Allen et al., 2020b) is based on likelihoods of observing a particular number of cases. For example, the number of observed cases in a cohort study is commonly modeled as coming from a Poisson distribution.

To deal with this requirement, adjusted counts of cases and controls (or cases and expected numbers) are computed which will be referred to as “effective count(s)” to avoid confusion with other adjustments that may be part of the analysis. The derivation of effective counts had one very specific goal: to construct a set of counts that reflects only the effect of arsenic. It attempts to construct a data set that would be as if all groups under consideration differed only with respect to arsenic dose but were uniform with respect to the other variables for which RR’s or OR’s were adjusted. As will be shown below, this involves adjusting so as to mimic data that might have been collected had all covariates (other than dose) in all groups been the same as those observed in the referent group. In the context of a case-control study, for example, the effective counts could be viewed as a single 2xG table (G = number of dose groups) of the effective counts of cases and controls which could be considered to represent what data one would have gotten from sets of individuals who were homogeneous with respect to other covariates. Therefore, “effective counts” are the data that would have resulted in the adjusted OR or RR values had confounding not occurred in the study population.

Calculation of effective counts has been the focus of multiple papers: Greenland and Longnecker (1992) reported on a method that retained original sample sizes but obtained the adjusted relative risks, Hamling et al. (2008) used a method that allowed sample sizes to change but resulted in the adjusted RRs and the standard error of the logRR, and Orsini et al. (2012) provided corrected equations for the variance of the logRR and concluded that either adjustment improved estimation (compared to using unadjusted counts). Both Greenland and Longnecker (1992) and Orsini et al. (2012) make clear that “relative risk” includes the metrics of OR, hazard ratio, etc., and so the methods can be applied to case-control studies, incidence rate studies, or cumulative incidence studies (see Rothman and Greenland (1998), for definitions of these study types, which are discussed further below). The definition of the variance terms for logRR varies across these study types, but they are all amenable to effective count calculations.

The term “effective count” refers to the fact that when making the adjustments to OR and RR, the impact of the other variables is removed. But the estimation of the associations between confounders and dose, and between confounders and the endpoint, “uses up” some of the degrees of freedom associated with the initial sample size. In essence, the approximation of the “otherwise homogeneous set of individuals” mentioned above results in a smaller sample size for evaluating just the arsenic effect. The magnitude of that effect depends (among other things) on how strongly the set of confounders for which RR’s or OR’s have been adjusted are associated with the arsenic dose and with the endpoint of interest (Rothman and Greenland, 1998).

In practice, one typically has two sources of information from published literature from which effective counts can be estimated. The first source consists of the values of the adjusted RR’s or OR’s themselves. The derived counts should result in the values of the adjusted ratios reported when one computes a “simple” ratio from the effective counts. The second source of information is obtained from estimates of the standard errors (or confidence limits) reported for the RR’s or OR’s (or for log (RR) or log(OR)). Examples will illustrate the procedure for effective count computation.

##### Incidence rate cohort study

This approach was implemented for cohort studies where observed numbers of cases and expected numbers of cases were presented (or derivable) and the study used an internal referent group for defining the relative risks. Consider the data shown in Table C-7, for the Chen et al. (2010b) dataset. The first group is the internal referent group (adjusted RR = 1 by definition).

Table C-7 Summarized data; cumulative incidence cohort study; Chen et al. (2010b)

Reported number of cases | Adjusted RR | 95% LCL on adjusted RR | 95% UCL on adjusted RR
6 | 1 | -- | --
3 | 1.11 | 0.27 | 4.54
12 | 2.33 | 0.86 | 6.36
5 | 3.77 | 1.13 | 12.6
11 | 7.49 | 2.7 | 20.8

Chen et al. (2010b) reported RRs based on person-years of follow-up through Cox proportional hazard methods, i.e., the study is an incidence rate (not incidence proportion or cumulative incidence) study (see first paragraph, p. 105 of Chen et al. (2010b)). Orsini et al. (2012) give the standard deviation of the logRR(i) values from such a study as:

S E ( log a d j u s t e d R R ( i ) ) = sqrt((1)/(C a s e s ( 0 )) + (1)/(C a s e s ( i ))) (C-6)

Here Cases(i) refers to the number of cases in group i, with the referent group being group 0. The number of cases in the referent group will be fixed; reasons for that decision are discussed at the end of this section. Then it is easy to solve for Cases(i) in Eq C-6 and then compute the expected^8^ number as (C a s e s ( i ))/(a d j u s t e d R R) .^9^ Derivation of a value for SE (logRR(i)) is based on the reported confidence limits for the logRR(i) values, as follows. The standard procedure for estimating a 95% upper confidence bound for RR’s is (Rothman and Greenland, 1998):

95 % u p p e r c o n f i d e n c e limit = e^( log ( a d j u s t e d R R ) + 1.96 × S E ( log ( adjusted R R ) )^ (C-7)

So that, by using the referent group and next group from the Chen et al. (2010b) study (see Table C-7),

4.54 = e^( log ( a d j u s t e d R R_1_ ) + 1.96 × S E ( log ( a d j u s t e d R R_1_ ) )^ = e^( log ( 1.11 ) + 1.96 × S E ( log ( a d j u s t e d R R ) )^

so

S E ( log ( a d j u s t e d R R_1_ ) ) = (log 4.54 − log 1.11)/(1.96)

from which Eq C-6 gives the effective count for Cases (1), which equals 2.84. In practice (and for results shown in Table C-8, for example), the results of using the upper bound and lower bound for the confidence interval are averaged to reduce the effect of round-off error in reported values. This is equivalent to equating the width of the confidence interval to 2 × 1.96 × SE (on the log scale). EPA computed the SE values for the two sides separately (and then averaged) as that facilitates the identification of errors or typographical mistakes in the reported values. The two SE estimates should be essentially the same, to the number of digits reported; if not, there may be an issue with the values reported. The expected effective count is given by:

E x p e c t e d e f f e c t i v e ( 1 ) = (C a s e s ( 1 ))/(A d j u s t e d R R) = (2.84)/(1.11) = 2.56 (C-8)

since, even with effective counts, adjusted RR = number of cases divided by expected number. The same procedure is followed for all the other dose groups. The results obtained for this example are displayed in Table C-8. Computation of RR using the effective cases and expected effective counts results in RR’s and confidence bounds that match those reported as “adjusted” values in Chen et al. (2010b), as was expected.

In this particular case, the effective counts for the cases are very similar to the raw counts. Adjustment for the other covariates had little effect on effective counts in this instance.

Table C-8 Effective data derived for incidence rate cohort study; Chen et al. (2010b)

Effective cases | Effective expected number | RR | 95% LCL on RR | 95% UCL on RR
6.00 | 6 | 1
2.84 | 2.56 | 1.11 | 0.27 | 4.54
10.65 | 4.57 | 2.33 | 0.86 | 6.36
4.72 | 1.25 | 3.77 | 1.13 | 12.6
9.56 | 1.28 | 7.49 | 2.7 | 20.8

##### Cumulative incidence cohort study

For some analyses (e.g., for the cardiovascular disease analysis), the type of cohort study dealt with is called a cumulative incidence study (Rothman and Greenland, 1998). In that case, the RR’s are ratios of the proportions of subjects getting bladder cancer; the data might be presented as in Table C-9.^10^ EPA used this approach when the modeling required proportions of individuals affected (i.e., where binomial likelihoods were required).

Table C-9 Example cumulative incidence cohort study results

Cases(i) | Sample size (N(i)) | Unadjusted | | Adjusted
Cases(i) | Sample size (N(i)) | RR | SE(log(RR)) | RR | SE(log(RR))
6 | 2,534 | 1 | | 1
3 | 1,120 | 1.13 | 0.71 | 1.11 | 0.72
12 | 2,078 | 2.44 | 0.50 | 2.33 | 0.51
5 | 524 | 4.03 | 0.60 | 3.77 | 0.62
11 | 632 | 7.35 | 0.51 | 7.49 | 0.52

The unadjusted RRs are simply equal to

( Cases ( i ) / N ( i ) ) / ( Cases ( 0 ) / N ( 0 ) ) (C-9)

where i indicates the group number and, again, group 0 corresponds to the referent group. The equation for SE(log(adjusted RR)) is

SE ( log ( adjusted RR ( i ) ) ) = sqrt [ 1 / Cases ( i ) − 1 / N ( i ) + 1 / Cases ( 0 ) − 1 / N ( 0 ) ] . (C-10)

Together, Eq C-9 and Eq C-10 define 2*n equations for 2*(n+1) unknowns.^11^ Two additional equations are required to specify the system. Extending our approach to the incidence rate studies discussed above, Cases (0) will be fixed to be the same as reported in the data (e.g., 6 for the data in Table C-7). In addition, the value of N(0) (the sample size in the referent group, 2,534 for Table C-9) will also be fixed. The rationale for that choice is discussed at the end of this appendix.

The algebra that yields estimates for Cases(i) and N(i) is relatively straight-forward. The calculations are automated in a spreadsheet provided in the Supplemental Material. For the example in Table C-9, the resulting effective counts are shown in Table C-10. As desired the adjusted RR’s and the confidence limits computed using the effective counts in Table C-10 match the corresponding “adjusted” values in Table C-9.^12^

Table C-10 Effective counts for example cumulative incidence cohort study

Adjusted cases | Adjusted N | RR | 95% LCL on RR | 95% UCL on RR
6.00 | 2,534 | 1
2.83 | 1,077.83 | 1.11 | 0.27 | 4.54
10.55 | 1,912.40 | 2.33 | 0.86 | 6.36
4.67 | 523.29 | 3.77 | 1.13 | 12.6
9.35 | 527.47 | 7.49 | 2.7 | 20.8

##### Case-control studies

Consider the data in Table C-11, obtained from a published report of case-control study of arsenic and bladder cancer (Meliker et al., 2010).

Table C-11 Reported case-control study results; Meliker et al. (2010)

Cases | Controls | Raw OR | Adjusted OR | 95% LCL on adjusted OR | 95% UCL on adjusted OR
189 | 252 | 1 | 1
162 | 234 | 0.92 | 0.83 | 0.62 | 1.11
43 | 48 | 1.19 | 1.01 | 0.62 | 1.64

Here, we want to replace the case numbers with effective counts (call them a_0_ to a_2_, for the three groups with 0 corresponding to the referent group as usual). Moreover, we want to replace the control numbers with effective counts (call them b_0_ to b_2_, for the three groups). As in the case of the cumulative incidence studies, there are 2n equations and 2(n+1) parameters to be estimated. Think of the data table being populated with variable names as follows (see Table C-12).

Table C-12 Basis for obtaining effective counts; case-control study; Meliker et al. (2010)

Cases | Controls | Adjusted OR | 95% LCL on adjusted OR | 95% UCL on adjusted OR
a0 | b0 | 1
a1 | b1 | 0.83 (OR1) | 0.62 | 1.11
a2 | b2 | 1.01 (OR2) | 0.62 | 1.64

By the definition of odds ratios, and of standard errors for log(OR), we know that we want, in this example,

a d j u s t e d O R_1_ = (b_0_ × a_1_)/(a_0_ × b_1_) = 0.83

a d j u s t e d O R_2_ = (b_0_ × a_2_)/(a_0_ × b_2_) = 1.01

Furthermore, the basis for the confidence limits (Rothman and Greenland, 1998) is in the following equations:

S E ( log ( adjusted O R_1_ ) ) = sqrt((1)/(a_0_) + (1)/(b_0_) + (1)/(a_1_) + (1)/(b_1_)) = 0.14

S E ( log ( adjusted O R_2_ ) ) = sqrt((1)/(a_0_) + (1)/(b_0_) + (1)/(a_2_) + (1)/(b_2_)) = 0.23

SEs are calculated from the confidence limits bounds, with the calculation based on the upper bound averaged with the corresponding calculation based on the lower bound, as was described for the cohort studies (Eq C-6 but with “OR” replacing “RR”). There are four equations for six unknowns (a0, …,a2, b0, …,b2), so two additional constraints must be specified. The first constraint is that a0 will be set to be equal to the observed number of cases in the referent group (189 in this example). The second constraint relates to the number of controls in the referent group, as a proportion of the total number of controls in the 3 groups. Specifically, b0 … b2 is specified to satisfy the equation:

(b_0_)/(( b_0_ + b_1_ + b_2_ )) = r_0_ . (C-11)

The resulting system of equations requires a relatively simple numerical solution.

In this example:

a_0_ = 189

r_0_ = (252)/(( 252 + 234 + 48 )) = 0.472

Table C-13 shows the resulting 3 × 2 table of effective counts that results from the procedure defined above. As desired, using the effective counts for computation results in the ORs and confidence limits shown in that table, and those values match the corresponding values in Table C-11.

Table C-13 Effective count results; case-control study; Meliker et al. (2010)

Cases | Controls | OR | 95% LCL on OR | 95% UCL on OR
189.00 | 210.37 | 1
145.13 | 194.62 | 0.83 | 0.62 | 1.11
37.01 | 40.79 | 1.01 | 0.62 | 1.64

The effect on the counts is a function of the difference between the raw and adjusted OR and SE(log(OR)) values. In this case, using the original counts (i.e., ignoring adjustments for covariables, Table C-11) the two standard errors (on the log scale) were.

S E ( log ( a d j u s t e d O R_1_ ) ) = sqrt((1)/(189) + (1)/(252) + (1)/(162) + (1)/(234)) = 0.14

S E ( log ( a d j u s t e d O R_2_ ) ) = sqrt((1)/(189) + (1)/(252) + (1)/(43) + (1)/(48)) s = 0.23.

These values are quite similar to the SE values derived from the reported adjusted OR confidence limits (0.15 and 0.25, respectively), reflecting little loss of precision associated with adjusting for other variables.

##### Rationale for constraints

Note that the methods EPA have used to derive effective counts differs from those proposed by either Greenland and Longnecker (1992) or Hamling et al. (2008). Our methods result in confidence limits that match those reported for adjusted values; the method of Greenland and Longnecker (1992) does not. Moreover, EPA uses different constraints than used by Hamling et al. (2008). The reasons for the different constraints are as follows. They relate to the observation in the introduction to this appendix section that pointed out that the adjustments are made so as to derive effective data that might have been collected had the covariate levels remained the same as in the referent group, for all groups. Thus, the original referent group characteristics are preserved to the extent possible. The Bayesian analysis perspective also influenced our choices.

For the incidence rate cohort studies, our adjustments preserve the original count of cases in the referent group, while still adjusting the counts in the other dose groups. That choice has been made based on the methodological decision to treat the referent group separate from the other cohort study groups. EPA derived priors for the Poisson expected value in the referent group using that group’s observations. That group was then not included in the likelihood contributions during subsequent parameter updating (so that those data were not “counted twice”). However, since priors were derived based on the observed count in the referent group, effective counts were derived so as to preserve the original number of cases in that group.

For the cumulative incidence studies, the characteristics of the referent group now include the group sample size as well as the number of cases. It was a natural extension of the option used with incidence rate studies to fix both the referent group cases and sample size.

For the case-control studies, calculation of the log-likelihood contributions for the Bayesian analysis requires an approximation to the distribution of dose in the population. That approximation depends on the proportions of controls across the various dose groups. Those proportions are not something that is affected by covariate adjustment. Therefore, EPA desired that the method used for effective counts in case-control studies retained as much of the discretized control group distribution as possible. It turns out that it was only possible (with a few rare exceptions) to fix the proportion of controls in the referent group.^13^ Thus, while retaining the fixed value of the referent group number of cases, EPA added the constraint that the proportion of controls in the referent group (relative to the total number of controls over all dose groups) be constant at the observed value.^14^ That latter constraint is one of those that was applied by Hamling et al. (2008).

The adjustments of counts for both case-control and cohort studies, and of expected values for incidence rate cohort studies, have been automated in R code (see Supplementary Material).

#### Bayesian Dose-Response Meta-Analysis Methods

Case-Control Studies: The modeling of case-control studies in a Bayesian context has been discussed by several authors (see Mukherjee et al. (2005) for a review of several situations and approaches). As described here, EPA has followed Gustafson et al. (2002) for the initial development of the approach used for this analysis.

It is assumed that the prospective likelihood is given by a logistic-power equation applied to a vector of p explanatory variables X = (X_1_, … , X_p_:

logit { Pr ( D = 1 | X ) } = α * + β^T^ s ( X^q^ ) (C-12)

where, by “prospective likelihood” means Pr(D = 1 | X), the probability of having the disease (D = ) as opposed to not having the disease (D = 0), conditional on the values of the explanatory variables, X. Here, s(X) = (s_1_(X), … , s_p_(X)) represents a possible transformation of the explanatory variables. Both α*(∈ ℝ) and β(∈ ℝ^p^) are parameters to be estimated. In the application of this method to iAs, EPA is interested in a single explanatory variable, X (a measure of arsenic dose) and we will not, for the time-being, be considering a transformation of that variable. So, p = 1 and s_1_(X) = X, so we will simply replace s(X) with X in Eq C-12 and refer to X as “dose.” The q parameter is the exponent on the explanatory dose variable x.

For a case control study, what is observed relates to the retrospective likelihood. That is, there is a sample (of size n_1_) of cases and then observe their doses, and similarly for the sample of controls (of size n_0_). Those observations correspond to the retrospective likelihoods f(X | D = 1) and f(X | D = 0), respectively.

Gustafson et al. (2002) have shown that, using Bayes theorem, the logistic form of the prospective likelihood of interest implies that:

ln (f ( x | D = 1 ))/(f ( x | D = 0 )) = α + β x^q^ (C-13)

where α = α* − logit{Pr(D = 1)}.^15^ Using Eq C-12, and assuming some density, h(X), for the dose distribution, it can be shown that.

f ( x | D ) = e^[ D { α + β x^q^ } ]^ h ( x ) (C-14)

This is the retrospective likelihood that needs to be modeled for case-control data. Note that

f ( x | D = 0 ) = h ( x ) (C-15a)

f ( x | D = 1 ) = e^[ α + β x^q^ ]^ h ( x ) (C-15b)

and note that, since f(x|D = 1) must itself be a density (must integrate to 1 over its support), this implies a constraint on the value of α. In fact, Gustafson et al. (2002) consider α to be a function of the other two “parameters,” α = α(β, h). They show that α is the solution to

E_h_ [ e^[ α + β X^q^ ]^ ] = 1 (C-16)

where E_h_ is the expectation with respect to X having density h(X). Therefore, the likelihoods needed for the Bayesian analyses depend on an unknown density h (as well as a parameter β). A decision regarding what to do about h(X) is needed in order to proceed.

One could define h(X) to be some relatively simple parametric form, such as a lognormal distribution. Given that assumption, and the observed proportions of the cases and controls falling within defined dose intervals, a mean and a variance for an underlying lognormal distribution could be estimated. This is similar to the assumption that was used to derive group-specific mean values described in Section C.1.1: Treatment of Dose Uncertainty.

One issue with such an approach is that there may be model misspecification with respect to the density of X. Furthermore, the solution for α using Eq C-16, even assuming a single lognormal distribution for dose in the cohort, entails evaluating the integral

∫_0_^∞^ (e^β x^)/(σ sqrt(2 π)) e^(− ( ln ( x^q^ ) − μ )^2^)/(2 σ^2^)^ d x (C-17)

which has no analytical solution.^16^ Numerical evaluation of α during an MCMC run is not tractable since that would require a numerical optimization within each step of the MCMC process.

Muller and Roeder (1997) implemented an approach to approximating h(X) through the use of more flexible models. They proposed defining h(X) as a mixture of normal distributions. That procedure is more complicated, and it does not remove entirely the possibility of misspecification. In an attempt to reduce the complexity (and the somewhat arbitrary choice of the number of distributions to include in the mixture, which must balance the relative merits of flexibility with those of tractability), EPA has adopted an approach based on that presented in Gustafson et al. (2002), which approximates h(X) with a discrete distribution.

This approach is particularly appealing in the context of analyses based on published reports for which the individual doses are not presented, i.e., where the observations are grouped into exposure-based intervals, but no information is available about how the exposures are distributed within or across those intervals. Suppose there are m dose intervals (c_0_, c_1_), (c_1_, c_2_),… , (c_m−1_, c_m_); c_0_ may equal 0 and c_m_ may equal ∞. Let λ_i_ be the (unknown) true proportion of the doses in the ith interval. We let λ be the m-dimensional simplex (a vector whose elements, λ_i_, sum to 1) (see Stan Development Team (2017), page 555) representing those proportions, and approximate h(X) by λ.

In that case, since every observation in interval i is assigned the same dose value, x_i_, Eq C-14 becomes

f ( x_i_ | D ) = e^[ D { α + β x_i_^q^ } ]^ λ_i_ (C-18)

and Eq C-16 becomes

Σ_i = 1_^m^ e^[ α + β x_i_^q^ ]^ λ_i_ = 1 (C-19)

(the integral over h(X) is replaced by the summation over the discrete probabilities). Eq C-19 is easily solvable for α:

α = − ln ( Σ_i = 1_^m^ λ_i_ e^[ β x_i_^q^ ]^ ) (C-20)

Therefore, the complicated numerical solution for α is avoided and the problem becomes tractable in an MCMC context, i.e., the likelihood contribution for each observation (Eq C-18), can be computed as a function of the values of β and λ. Note that since h(X) represents the density of doses given no disease (D = 0), as per Eq C-15a, one would use the dose information from controls as the basis for λ estimation (though, of course, Eq C-18 defines the likelihood contribution for both cases and controls).

At this point, there are two options for defining λ for the Bayesian analyses. The first option, and the one adopted in these analyses, would be to assign a prior for λ and proceed with the MCMC-based updating of λ and the other parameters. Gustafson et al. (2002) have suggested a Dirichlet prior for λ:

(1)/(B ( a )) Π_i_ λ_i_^a_i_ − 1^ (C-21)

where B(a) is the multivariate Beta function. In particular, the “flat Dirichlet” distribution, for which a_i_ = 1 (all i), gives equal prior density to all values of λ and in that sense is uninformative with respect to λ.

Note that this option can yield λ_i_ estimates that are not consistent with any simple parametric density, and in particular not consistent with the lognormal distribution which might be used to characterize the distribution of dose values in the study population. In that sense it is more flexible with respect to “fitting” the dose distribution that underlies the observed (interval-censored) data. On the other hand, because this option is separate from a characterization of the underlying distribution of doses in the study population, it is uninformative with respect to estimation of the values of x_i_ that go into the likelihood computations (C-18).

Cohort Studies: Given the logistic model basis for the case-control studies and the likelihoods derived therefrom, there are certain constraints imposed on the modeling framework for cohort studies, if one wants to include both types of studies in a meta-analysis. The following discussion describes the development of the corresponding dose-response modeling and likelihood contributions for cohort studies (specifically, in this example, for cumulative incidence studies; see Rothman and Greenland (1998) and Orsini et al. (2012)). The logistic form entails that

Pr ( D = 1 | X ) = (1)/(1 + e^( − α * − β X^q^ )^) (C-22)

Let

θ = Pr ( D = 1 | X = x_1_ ) = (1)/(1 + e^( − α * − β x_1_^q^ )^) (C-23)

where x_1_ is the dose for the referent group in the study under consideration. Continuing the notation introduced above, with dose intervals (c_i-1_, c_i_) (i = 1, …, m) defining the grouping of the data, x_1_ is the dose assigned to the group corresponding to (c_0_, c_1_). θ is an unknown; it must be estimated. Or, in the Bayesian context, it is a parameter for which a prior is assigned (see below). That prior will be updated through the MCMC method.

For any other group defined by the categorization of the results, say for the ith group defined by (c_i-1_, c_i_), having n_i_ subjects and a dose associated with it of x_i_, the expected value for number of cases would be

μ_i_ = n_i_ × (1)/(1 + e^( − α * − β x_i_^q^ )^) = n_i_ × θ × (1 + e^( − α * − β x_1_^q^ )^)/(1 + e^( − α * − β x_i_^q^ )^) (C-24)

by the definition of θ (Eq C-23). Now note that for group i, μ_i_ = n_i_ × θ, the number of subjects in the group times the probability of response, is the expected number of cases for the ith group, as is typically computed for a cohort study (i.e., with no dose-response modeling, but including adjustments for covariables) had the probability of response for the referent group been θ.

Eq C-24 completely defines the format to be used for the analysis of cohort studies where the expected number of cases associated with a dose group are given, or can be derived, and that expected number is based on the referent group probability of response, θ.^17^

In a published report for an internally standardized cohort study, one with a referent group that has a relative risk of 1, by definition, the expected numbers for all the groups appear to be based on the observed number in the referent group. For example, that is why the reported expected value for the referent group is always equal to the observed number in that group (because that is the MLE for the expected number). In actuality, however, it is the expected number in the referent group that determines the expected number reported for the other groups. This has the consequence that the reported expected values in a publication need to be treated not as constants, but as derived variables.

This has been handled in the current analyses by separating out the referent group from the other dose groups. A prior for μ^′^_1_ was defined independent of the other dose groups (see below) and μ^′^_1_ is included as a parameter in the model. Then the Bayesian analysis used only the remaining dose groups to update the model parameters, including μ^′^_1_ .

However, there are two issues that we must deal with in order to complete the development of the extension to cohort studies.

First, the relationship between the reported expected number for the referent group and the reported expected number in any other group is not a simple relationship like that given for case-control studies (Eq C-24). For case-control studies, the expected number for another group, given an estimate of the expected number in the referent group, was simply proportional to the latter. That is not necessarily the case for the cohort study, where the expected value depends not only on the referent group expected value but also on differences in the patterns of person-years of follow-up. If the individual follow-up data were available, that relationship could be defined explicitly. But it is often the case that individual data are not available for a number of reasons, and methods must be developed that recognize this common limitation.

Published, internally standardized cohort studies use the observed number in the referent group, O_1_, to compute all the expected values in the other groups. Those presented (or derivable) expected values, we will call RE_i_ (“Reported Expected” value for group i > 1). So, the simplifying assumption is that the expected values for a non-referent group will be defined by

μ_i_^'^ = R E_i_ × (μ_i_^'^)/(O_1_) (C-25)

This borrows from the case-control situation, the proportionality for expected numbers in relation to the observed number of cases in the referent group. That assumption may be appropriate when μ_1_ is close to O_1_. The prior for μ^′^_1_ is lognormal, centered on O_1_ (see below); this will tend to push μ_1_ toward O_1_, further supporting the proportionality assumption.

Second, unlike θ (which can be derived from α* and β parameter estimates, Eq C-23), μ^′^_1_ for a cohort study is not expressed in terms of the model parameters. So, for every internal-referent cohort study, we are adding a parameter to the meta-analysis model. On the other hand, as shown here, the parameter α* can be derived from proposed μ^′^_1_ and β values, if we have one other piece of information from the cohort study: the person-years of observation for the referent group, PY_1_.

That is the case because

μ_1_^'^ = P Y_1_ × (1)/(1 + e^( − α * − β x_1_^q^ )^) (C-26)

so that

α * = − ln ( (P Y_1_)/(μ_1_^'^) − 1 ) − β x_1_^q^ (C-27)

Putting together Eqs C-23 and C-24, the equation for μ_i_ becomes

μ_i_ = R E_i_ × (μ_1_^'^)/(O_1_) × (1 + e^( − α * − β x_1_^q^ )^)/(1 + e^( − α * − β x_i_^q^ )^) (C-28)

with α* computed via Eq C-27.

The prior for μ^′^_1_ is defined as follows. Given O_1_, and assuming that the observations are Poisson distributed with a mean equal to μ^′^_1_ , we derived the MLE, and 95% upper confidence bound for μ^′^_1_ . The 95% confidence bound is computed based on profile likelihood methods (Cole et al., 2014). Then, a lognormal distribution was defined such that the median of that distribution is equal to the MLE value and the 95th percentile of that distribution was equal to the 95% upper confidence bound. That lognormal distribution was the prior used in the Bayesian analysis.

Implementation: Given the above development, the implementation of the Bayesian meta-analysis was completed using RStan (version 2.9), a package in R that calls and executes code written in the Stan language (Stan Development Team, 2017). This section highlights the implementation of the methods described above for case-control and cohort studies.

The primary steps in the RStan model consist of the following:

- Reading in the study data (R code); defining variables for Stan (“Data” section of Stan code);
- Defining parameters β and λ, for case-controls studies; or β and μ^′^_1_ , for cohort studies (“Parameters” section of Stan code);
- Setting priors for β and λ or μ^′^_1_ (“Model” section of Stan code);
- Calculating the parameter α or α* (“Model” section of Stan code);
- Defining the log-likelihood contributions for each dose group (“Model” section of Stan code).

With respect to the final step, the log-likelihood contributions are explicitly defined as follows. Recall from the discussion of case-control studies above, that Eq C-18 shows the likelihood contribution for a single case (D = 1) or control (D = 0). Taking the log of Eq C-18, the log-likelihood contribution for an observation that is a case in group i (i = 1, …, m) is α + βx_i_ + ln(λ_i_); for a control observation, the contribution is ln(λ_i_). Therefore, for dose group i the total contribution is

c a s e s [ i ] × { α + β x_i_^q^ + ln ( λ_i_ ) } + c o n t r o l s [ i ] × ln ( λ_i_ ) (C-29)

where cases[i] and controls[i] are the number of cases and controls, respectively, in group i. That total contribution is what is used in the Stan “Model” section. Note that this formulation will work even if cases[i] and controls[i] are not integers (which may occur when effective counts are computed to adjust for possible confounders).

Similarly, for a cohort-study, non-referent dose-group, i, with dose = x_i_,^18^ where the number of cases is assumed to arise from a Poisson distribution, with mean, μ_i_, given by Eq C-18, the log-likelihood for such a group is

l l_i_ = − μ_i_ + O_i_ × ln ( μ_i_ ) (C-30)

The log-likelihood for cohort studies is based on a continuous extension of the Poisson distribution. This extension allows one to consider non-integer inputs to the Poisson distribution, such as the effective counts that were derived to account for adjustment to the reported RRs. The continuous Poisson extension is described in Turowski (2010) and Kim et al. (2010). In essence the usual factorial normalizing constant is replaced by the Gamma function equivalent (k! = Γ(k + 1), which is defined for non-integer values, and which allows the continuous Poisson distribution to integrate to 1 over the range of non-negative values. The kernel of the continuous distribution, however, is the same as for the regular Poisson distribution, i.e., μ^x^ · e^−μ^, where μ is the single parameter of the model. Taking the log of that and ignoring the resulting additive terms that do not depend on the parameter value leads to the log-likelihood as shown in Eq C-30. Ilienko (2013) proposes a different extension of the Poisson distribution, but it was considered impractical for implementation in the context of MCMC analyses.

Dose-response plots that that display the mean and 95% credible intervals for the fitted model predictions for the individual studies serve as the basis for posterior predictive plots and examining goodness-of-fit. Those plots have been generated without the hierarchical structure in order to avoid the tendency for the study-specific estimates to be pushed toward the hierarchical mean of the slope parameter. But, otherwise, they represent the posterior predictions, on a study-by-study basis, relative to the observed odds ratios (for case-control studies) or relative risks (for cohort studies). When the frequentist-based confidence intervals for the study-reported ORs or RRs fall outside of the credible interval for the model-predicted response for an individual study, the high dose for that study is dropped and the dataset remodeled to determine if the model predictions credible intervals and study-reported confidence intervals then overlap. Convergence statistics such as the RHat variable and effective N (i.e., sample size) are also considered.

#### Estimation of Lifetime Extra Risk in the U.S. (Lifetable Analysis Methods)

This method follows a typical lifetable analysis (Rothman and Greenland, 1998; Crump and Allen, 2011) but includes consideration of the background exposure in the target population.

Consideration of background exposure in the lifetable calculations was considered critical for iAs given there is no population with zero exposure to iAs. For the health outcomes evaluated in this assessment, EPA assumes that the estimated background exposure level is associated with a median U.S. background iAs dose of 0.0365 µg/kg-day, consisting of a 0.02 µg/kg-day contribution from diet (Xue et al., 2010), a 0.0165 µg/kg-day contribution from drinking water, and no contribution from inhalation exposures. The estimated drinking water contribution assumes a median background drinking water level of 1.5 µg/L (Mendez et al., 2017) and a water consumption rate of 0.011 L/kg-day (U.S. EPA, 2019, Table 3-1, “All Ages”). According to the available physiologically based pharmacokinetic model for arsenic (El-Masri and Kenyon, 2008), this 0.0365 µg/kg-day inorganic arsenic dose is equivalent to a total urinary arsenic level of approximately 2 µg/L, which is within the 1–5 µg/L background range estimated by the (NRC, 2013).

In general, the probability of disease occurrence (morbidity and/or mortality) between ages t_1_ and t_2_ (given survival to age t_1_), given an age-specific exposure pattern DP, may be expressed as:

p ( t_1_ , t_2_ , D P ) = ∫_t_1__^t_2_^ h a z ( t , D P ( t ) ) S ( t , D P ( t ) ) d t (C-31)

where haz(t, DP(t)) is the instantaneous hazard of disease occurrence and S(t, DP(t)) is the probability of survival to age t_2_ given survival to age t_1_ and exposure pattern DP(t).

At the background exposure level, b, this integral can be approximated by a sum:

p ( b ) = Σ_i = 1_^n^ p ( i ) S ( i ) (C-32)

where the age interval [t_1_, t_2_] has been divided into n subintervals with the i^th^ subinterval having width Δ(i), i = 1, … , n; p(i) represents the probability of disease occurrence in the i^th^ age interval; and S(i) represents the probability of surviving to the beginning of the i^th^ age interval. The quantity p(i) is calculated as:

p ( i ) = q_c_ ( i ) Δ ( i ) (C-33)

where q_c_(i) is the endpoint-specific rate of occurrence. The quantity S(i) is calculated as S(0) = 1 and:

S ( i ) = Π_j = 0_^i − 1^ q_a_ ( j ) Δ ( j ) , i ≥ 1 (C-34)

where q_c_(j) and q_a_(j) are, respectively, the endpoint-specific rate of occurrence and all-cause death rates for the jth age interval. These rates can be obtained from standard rate tables.

If the subintervals correspond to individual years, Eqs. C-32 and C-34 take on the simplified forms:

p ( b ) = Σ_i = t_1__^t_2_^ q_c_ ( i ) S ( i ) (C-35)

and

S ( i ) = Π_j = t_1__^i − 1^ q_a_ ( j ) (C-36)

Once the background rates q_c_ and q_a_ are obtained and after setting t_1_ = 0 and t_2_ = 85, these equations completely determine p(b), the lifetime probability of response at the background level of exposure over an assumed lifetime of 85 years.^19^

In addition to considering background exposure, these same formulae are used to calculate the probability of response, p(DP), from a particular exposure pattern, DP, by computing the endpoint-specific occurrence and all-cause mortality rates in such a way that accounts for the model-predicted effect of exposure on these rates. The appropriate modifications depend upon the form of the dose-response model estimated from the epidemiological data, and the assumed exposure pattern, DP. If the dose-response model predicts relative risk as a function of some exposure metric, then the endpoint-specific occurrent rate becomes q_c_(i)R(i), and the all-cause mortality rate becomes

q_a_ ( i ) − q_c_ ( i ) + R ( i ) q_c_ ( i ) = q_a_ ( i ) + q_c_ ( i ) [ R ( i ) − 1 ] (C-37)

where q_c_(i) and q_a_(i) are obtained from standard rate tables and R(i) is the relative risk predicted by the dose-response model, for age i, associated with exposure pattern DP. The modified all-cause mortality rate follows from subtracting the background rate from the disease of interest from the total death rate and adding back this contribution adjusted by the effect of exposure.

By setting DP to zero, one can estimate p(0), the lifetime probability of response in the absence of exposure. Once p(0) has been calculated, the extra risk above zero dose from exposure pattern DP is computed as:

(p ( D P ) − p ( 0 ))/(1 − p ( 0 )) (C-38)

The benefit of those assumptions is that p(b) in the above equations does not represent zero total iAs intake, but rather zero “extra” iAs intake. It is possible therefore to consider the impact of both positive changes (additional sources of iAs above background) and negative changes (circumstances with iAs exposures lower than the estimated background) on lifetime cancer risks. This is analogous to the treatment of the studies that were analyzed in the meta-analysis: the effect was assessed relative to their specific referent intake (or dose) values. And, in fact, the expressions in the form of Eq C-34 were used (with the pooled estimate of the logistic-power slope parameter, β and power parameter, q) along with a referent intake set equal to 0.0365 µg/kg-day, and α* derived from the lifetables for the U.S. population.

The R code developed to implement the approach is provided in the arsenic dose-response supplemental files (U.S. EPA, 2025), which are accompanied by an explanatory structured workflow, outline, and variable dictionary (U.S. EPA, 2024b).

##### Example of application of lifetable methodology

In the example below, variables are defined as listed in the variable dictionary (U.S. EPA, 2024b). First, consider the age-stratified bladder-cancer mortality and morbidity and all-cause mortality data (see Table C-14):

Table C-14 Lifetable rates for all-cause mortality and bladder cancer mortality and incidence

Age range | All-cause mortality (per 100,000)^a^ | Disease mortality (per 100,000)^b^ | Disease morbidity (per 100,000)^b^
0–1 | 567 | 0 | 0
1–4 | 24.3 | 0 | 0
5–9 | 11.6 | 0 | 0
10–14 | 15.5 | 0 | 0
15–19 | 51.5 | 0 | 0.1
20–24 | 95.6 | 0 | 0.2
25–29 | 121 | 0 | 0.4
30–34 | 145.4 | 0 | 0.7
35–39 | 173.8 | 0.1 | 1.4
40–44 | 218.4 | 0.3 | 2.7
45–49 | 313.2 | 0.6 | 6
50–54 | 488 | 1.4 | 12.6
55–59 | 736.5 | 3.2 | 23.8
60–64 | 1,050.2 | 5.8 | 41.5
65–69 | 1,473.5 | 9.5 | 68.6
70–74 | 2,206.9 | 16.7 | 100.2
75–79 | 3,517.8 | 27 | 135.4
80–84 | 5,871.7 | 47.8 | 165.2

a National Vital Statistics Report, Volume 68, Number 9, 2/16/2016. Final data for 2017: https://www.cdc.gov/nchs/data/nvsr/nvsr68/nvsr68_09-508.pdf.

b SEER cancer statistics for 2017: https://gis.cdc.gov/Cancer/USCS/DataViz.html.

From this data, define the incidence rate of disease for each age:

r_d i s e a s e_ ( a ) = (d i s e a s e m o r b i d i t y ( a ))/(100,000) (C-39)

Next, define the removal rate due to disease for each age, a = 0, … , A:

r_r e m o v a l_ ( a ) = (m o r t a l i t y ( a ) − disease mortality ( a ) + disease morbidity ( a ))/(100,000) (C-40)

Next, define the survival rate for each age:

r_s u r v i v a l_ ( a ) = { 1 , i f a = 0 1 − r_r e m o v a l_ × r_s u r v i v a l_ ( a − 1 ) , i f a > 0 (C-41)

Next, define the lifetime probability of disease:

Pr ( D ) = Σ_a = 0_^A^ ( r_s u r v i a l_ ( a ) × r_d i s e a s e_ ( a ) ) (C-42)

According to these calculations, the lifetime probability of bladder cancer in the U.S. is estimated to be 0.01897.

Next, to estimate the bladder cancer risk probability and risk while accounting for arsenic exposure, consider the relationship between bladder cancer and arsenic exposure using the results of the logistic-power model (see Table C-15).

Table C-15 Logistic-power model estimates for study and pooled slope and confidence intervals

Study | Lower_bound (5th percentile) | Slope | Upper_bound (95th percentile)
Chen et al. (2010b) | 0.036194 | 0.08069 | 0.126596
Steinmaus et al. (2013) | 0.260343 | 0.454837 | 0.657238
Wu et al. (2013) | 2.160251 | 2.955715 | 3.752163
Bates et al. (1995) | –1.86722 | 0.432051 | 2.772103
Steinmaus et al. (2003) | –2.24844 | –0.31315 | 1.442423
Bates et al. (2004) | –0.29556 | –0.15717 | –0.03761
Meliker et al. (2010) | –0.89816 | 0.158679 | 1.194132
Baris et al. (2016) | –0.08443 | 0.994007 | 2.118017
Chang et al. (2016) | 0.024232 | 0.095561 | 0.173531
Karagas et al. (2004) | –1.98641 | 0.336927 | 2.634965
Michaud et al. (2004) | –1.65652 | 0.52478 | 2.797245
pooled | 0.004076 | 0.369351 | 1.025257

The power parameter (q) estimated for bladder cancer via dose-response modeling is not hierarchical and was estimated to be 1.0890. The background dose of arsenic in the U.S., d_b_, is assumed to be 0.0365 µg/kg-day.

Define the incidence rate for each age, a, and dose, d:

r_d i s e a s e_ ( a , d ) = (1)/(1 + exp ( − α − β × d^q^ )) (C-43)

where

α = α * − β × d_b_^q^ (C-44)

and

α * = − ln ( (1)/(r_d i s e a s e_ ( a )) − 1 ) (C-45)

Next, define the removal rate for each age and dose:

r_r e m o v a l_ ( a , d ) = (1)/(1 + exp ( ln ( (1)/(r_d i s e a s e_ ( a )) − 1 ) + β ( d_b_^q^ − d^q^ ) )) (C-46)

Define the survival rate for each age and dose:

r_s u r v i v a l_ ( a , d ) = { 1 , i f a = 0 1 − r_r e m o v a l_ ( a , d ) × r_s u r v i v a l_ ( a − 1 , d ) , i f a > 0 (C-47)

From this, the lifetime probability of disease at dose d can be calculated:

Pr ( D | d ) = Σ_a = 0_^A^ ( r_s u r v i a l_ ( a , d ) × r_d i s e a s e_ ( a , d ) ) (C-48)

The extra risk of disease is defined as:

ER ( d ) = (Pr ( D | d ) − Pr ( D | d = 0 ))/(1 − Pr ( D | d = 0 )) (C-49)

Extra risks are calculated for the mean effect of β and the 5th and 95th percentiles for the overall effect of arsenic exposure across studies, i.e., “pooled,” as well as for individual studies. Lifetime extra risks can be calculated for any dose of interest; here (see Table C-16), lifetime extra risks are calculated for doses ranging from 0 to 1.0 µg/kg-day as this range is most relevant to real-world applications in the U.S.

Table C-16 Pooled dose-response meta-analysis estimates of extra lifetime bladder cancer incidence risk (per 10,000) at various average daily iAs doses using MLE doses^a,^ ^b^

Extra lifetime risk estimates (per 10,000)^a^ | Average inorganic arsenic dose (µg/kg-day)^b^
Extra lifetime risk estimates (per 10,000)^a^ | 0 | 0.0365^b^ | 0.1 | 0.13 | 0.2 | 0.3 | 0.4 | 0.5 | 0.6 | 0.7 | .08 | 0.9 | 1.0
5th % | 0 | 0.002 | 0.06 | 0.08 | 0.13 | 0.21 | 0.29 | 0.36 | 0.44 | 0.53 | 0.61 | 0.69 | 0.78
Mean | 0 | 1.96 | 5.88 | 7.87 | 12.80 | 20.50 | 29.00 | 38.32 | 48.53 | 59.72 | 72.00 | 85.47 | 100.28
95th % | 0 | 5.66 | 16.76 | 22.4 | 36.66 | 59.36 | 85.09 | 114.35 | 147.57 | 184.38 | 225.41 | 272.16 | 324.20

a Extra lifetime risks are presented as mean risk with 5%–95% probabilities based on mean, 5% and 95% estimates of dose-response slopes.

b Doses used in EPA modeling. U.S. daily background dose is estimated at 0.0365 µg/kg–day, 0.02 µg/kg–day from diet, 0.0165 µg/kg–day from water and 0 µg/kg–day from air (see Section 4.3.4).

#### Sensitivity Analysis of Possible Non-monotonic Dose-Response Relationships

##### Introduction

The primary meta-analyses take advantage of the fact that a logistic model form is suitable for modeling both cohort and case control studies. Moreover, they assume a particular relationship of the form.

logit { Pr ( D = 1 | d ) } = α * + β ∗ d^q^ (C-50)

where Pr (D = 1|d) is the (prospective) probability of response (D, disease state equals 1) at dose d, and α, β, and q are parameters that are estimated. In the context of the meta-analyses, a separate and independent α value was assumed for each study. The parameter β was hierarchical; study specific β values were distributed normally around a mean (or “pooled”) β parameter value.

One salient feature of such a model is that it describes a monotonic increase in probability of response as dose increases, for all positive doses. An example of such behavior for that model is shown in Figure C-3.

Figure C-3 Odds ratio for simple logistic model (i.e., q = 1) using d = 0.071 as reference.^20^

It has been suggested that inorganic arsenic and other ubiquitous elements might have a non-monotonic, hormetic effect on the probability of response for some endpoints, in particular for some cancer endpoints (Calabrese and Agathokleous, 2021). The sensitivity analysis reported here seeks to address that question by using some potentially non-monotonic relationships in place of the simple linear relationship on the right-hand-side of Eq C-50.

The goals of this analysis are as follows:

- First, determine if non-monotonic functions fit the data any better than the simple, monotonic, logistic relationship given above.
- Second, if they do fit better, determine if they entail an actual non-monotonic relationship, in the range of doses of interest.
- Third, regardless of the relative merits of the non-monotonic relationships, determine the effect on the risk estimates of interest. In this case, those risk estimates are expressed in terms of extra lifetime risk of the endpoint in question at several doses selected because of possible regulatory interest or importance. In all instances, the extra risk estimates are expressed in relation to the average inorganic arsenic in the U.S. (here assumed to be 0.071 μg/kg-day).

A Bayesian hierarchical modeling approach has been adopted to complete the sensitivity analysis. Details of that methodology are described below.

##### Classes of non-monotonic models under consideration

This sensitivity analysis addresses the effects using curve shapes other than the exponential model, including allowing for the possibility of non-monotone relationships that allow for, but do not necessarily result in, curve shapes that lead to a reduction in risk at low doses (from some non-zero risk at 0 dose) followed by an increase in risk at some somewhat higher doses. The particular forms investigated fall into two categories: fractional polynomial models and “double Hill” models.

Fractional polynomials have been proposed (Bagnardi et al., 2004) as a flexible set of equations that can assume a variety of shapes, including non-monotonic shapes. In the context of the current logistic regression, they are defined as follows:

logit { Pr ( D = 1 | d ) } = α * + b_1_ d^p_1_^ + b_2_ d^p_2_^ (C-51)

with the following provisions:

- p_1_ and p_2_ are selected from the set {0, 0.5, 1, 2, 3}
- if p_i_ = 0, then d^pi^ = ln(d)
- if p_1_ = p_2_ = p, then the equation becomes logit{Pr (D = 1|d)} = α* + b_1_d^p^ + b_2_d^p^ln(d).^21^

An illustrative example of the non-monotonicity induced by a fractional polynomial model is displayed in Figure C-4.

Figure C-4 Example non-monotonic dose-response relationship for fractional polynomial model

The double Hill models are, as the name suggests, a combination of two Hill models and thus have the form.

logit { Pr ( D = 1 | d ) } = α * + v_1_ ∗ d^p_1_^ / ( k_1_^p_1_^ + d^p_1_^ ) + v_2_ ∗ d^p_2_^ / ( k_2_^p_2_^ + d^p_2_^ ) . (C-52)

When v_1_ is positive and v_2_ is negative, this can (but does not necessarily) lead to non-monotonicity. All of the double Hill modeling reported here is restricted to that particular combination (v_1_ positive and v_2_ negative), for the pooled values of those parameters (see below for specifics about the hierarchical structure of the modeling). In the current sensitivity analysis, four such models have been investigated by restricting values of p_1_ and p_2_ to be 1 or 2 (so that there are 4 distinct combinations).

An example of the non-monotonicity induced by the double Hill model is displayed in Figure C-5.

Figure C-5 Example non-monotonic dose-response relationship for double Hill model

##### Details and issues related to defining the non-monotonic models

The fractional polynomial models have the potential to lead to curve shapes that approach infinite odds ratios for very small doses, i.e., for doses approaching zero, when a nonzero reference dose is used. The reference dose considered here (as it was for the simple linear logistic model) was set to 0.071 μg/kg-day. Given that possible behavior, which is considered to be biologically unreasonable, models of this form should generally not be extrapolated to very low doses. Specific measures were taken to mitigate the possibility of very large odds ratios for dose values less than but relatively “close to” that reference dose value. The approach taken for the fractional polynomial models was to define a parameter, called ln_OR_low, the log of the odds ratio at a low dose, which constrained its value to be reasonable, a priori. Specifically, the low dose used to define ln_OR_low was set to 0.00071 µg/kg–day, 100 times less than the reference dose of 0.071 μg/kg-day. In a sense, this choice reflects the fact that we want to examine the model predictions down to a certain relatively low dose value, a value in this case defined in terms of the target population of interest for this risk assessment (that being the US population) and that in order to rely on them, we want to ensure that the model predictions there are “reasonable.” Our definition of reasonable is that ln(OR) (using the US background of 0.071 µg/kg–day as the reference) is close to 0 (OR close to 1) down to 0.071/100. Thus, the prior for ln_OR_low has been defined to be Normal (0, 0.5). This entails that, a priori, we think the OR at 0.00071 µg/kg–day is highly likely (i.e., with about 95% probability) to be between exp(−1) = 0.37 and exp(1) = 2.7. As long as we restrict attention (extrapolation) to doses greater than 0.00071 µg/kg–day, the model results should not “blow up.”

The other constraint imposed on the fractional polynomial models was that, at and above some (undefined) dose level, the ORs should be increasing as dose increases. Given the various forms that the fractional polynomial models can take (see Eq C-51 above), this entailed identifying the parameter, b1 or b2, that dominated in the high dose region and setting a prior for that parameter to ensure such monotone increasing behavior at some dose level. Note that that prior assumption implied nothing (in general) about the direction of the slope of the risk curve at all doses, in particular at low doses. Depending on the model form and values of the parameters in it, this prior specification may be compatible and consistent with U-shaped or J-shaped curves, as long as those curves do increase at and above some (again, unknown) dose level.

To that end, the 35 fractional polynomial models that we considered have been subdivided into 6 subsets defined as follows:

Set A: p1 > p2. Subsets: Aneg: p1 < 0; Apos: p1 > 0

Here is a schematic defining the particular combinations of p1 and p2 that are in each of the A subsets:

| | p_2_
Set A | p_1_ > p_2_ | | −2 | −1 | −0.5 | 0.5 | 1 | 2
| p_1_ | −1 | Aneg
| p_1_ | −0.5 | Aneg | Aneg
| p_1_ | 0.5 | Apos | Apos | Apos
| p_1_ | 1 | Apos | Apos | Apos | Apos
| p_1_ | 2 | Apos | Apos | Apos | Apos | Apos
| p_1_ | 3 | Apos | Apos | Apos | Apos | Apos | Apos

Set B: p2 = 0. Subsets: Bneg: p1 ‘;’<0; Bpos: p1 > 0

Here is a schematic defining the particular combinations of p1 and p2 that are in each of the B subsets:

Set B | p_2_ = 0 p_1_ = | −2 | −1 | −0.5 | 0.5 | 1 | 2 | 3
| | Bneg | Bneg | Bneg | Bpos | Bpos | Bpos | Bpos

Set C: p1 = p2 = p. Subsets: Cneg: p < 0; Cpos: p > 0

Here is a schematic defining the particular combinations of p1 and p2 that are in each of the C subsets:

Set C | p_1_ = p_2_ = | −2 | −1 | −0.5 | 0.5 | 1 | 2 | 3
| | Cneg | Cneg | Cneg | Cpos | Cpos | Cpos | Cpos

Each subset of the fractional polynomial model group has its own pair of R and Stan programs to implement it. Table C-17 defines how the priors were defined for each of those subsets. Again, those priors guaranteed a curve that eventually would yield increasing risk as dose increased.

Table C-17 Listing of fractional polynomial model runs

Subset: | Hierarchical parameter | Prior for other parameter | Notes
Subset: | Hierarchical parameter | Prior for other parameter | One parameter hierarchical, the other constrained to give increasing dose-response at high doses
Aneg | b_2_[nstudies] ~ N(f_a_(ln_OR_low, b_1_), bsigma) | b_1_ ~ negative half-Normal(0, 10) | (# models = 3)
Apos | b_2_[nstudies] ~ N(f_a_(ln_OR_low, b_1_), bsigma) | b_1_ ~ positive half-Normal(0, 10) | (# models = 18)
Bneg | b_1_[nstudies] ~ N(f_bn_(ln_OR_low, b_2_), bsigma) | b_2_ ~ positive half-Normal(0, 10) | (# models = 3)
Bpos | b_2_[nstudies] ~ N(f_bp_(ln_OR_low, b_1_), bsigma) | b_1_ ~ positive half-Normal(0, 10) | (# models = 4)
Cneg | b_1_[nstudies] ~ N(f_cn_(ln_OR_low, b_2_), bsigma) | b_2_ ~ negative half-Normal(0, 10) | (# models = 3)
Cpos | b_1_[nstudies] ~ N(f_cp_(ln_OR_low, b_2_), bsigma) | b_2_ ~ positive half-Normal(0, 10) | (# models = 4)

f_a_(ln_OR_low, b_1_) = (ln_OR_low - b_1_*pow(0.071,p_1_)*(−1.0 + pow(0.01, p_1_)))/(pow(0.00071,p_2_)-pow(0.071, p_2_)).

f_bn_(ln_OR_low, b_2_) = (ln_OR_low - b_2_*log(0.01))/(pow(0.071,p_1_)*(−1.0 + pow(0.01, p_1_))).

f_bp_(ln_OR_low, b_1_) = (b_1_*pow(0.071,p_1_)*(−1.0 + pow(0.01, p_1_))-ln_OR_low) / log(100).

f_cn_(ln_OR_low, b_2_) = (ln_OR_low - b_2_*(pow(0.00071,p_1_)*log(0.00071)-pow(0.071, p_1_)*log(0.071)))/(pow(0.00071,p_1_)-pow(0.071, p_1_)).

f_cp_(ln_OR_low, b_2_) = (ln_OR_low-b_2_*(pow(0.00071,p_1_)*log(0.00071)-pow(0.071, p_1_)*log(0.071)))/(pow(0.00071,p_1_)-pow(0.071, p_1_)).

In all cases: prior for bsigma is positive half-Cauchy(0,20); prior for ln_OR_low is N(0, 0.5).

For the case of the double Hill models, there is no fear of risks increasing towards infinity as dose decreases towards zero. That is because the value of the two Hill functions is always equal to 0 when dose = 0, regardless of the values of the parameters v_i_, k_i_, and p_i_ (i = 1,2; see Eq C-52). For this reason,^22^ the parameterization of the double Hill models was based on the “natural” parameters v_i_, and k_i_ (the power parameters were fixed within each run to be either 1 or 2). The priors for the two ki parameters were the same, half-Cauchy (0, 300) restricted to positive values. The prior for v_1_ was half-Cauchy (0,20), restricted to be positive; for v_2_ it was half-Cauchy (0,20) but restricted to be negative. As discussed earlier, the combination of a positive v_1_ and a negative v_2_ is the only way to achieve a nonmonotonic curve shape, although even that combination does not force nonmonotonicity.

For the double Hill models, we did not constrain v_1_ to be greater (in absolute magnitude) than v_2_, it was possible (and the implementations did result in) curves that would result in ORs less than 1 for some high doses. As these tendencies were all for doses much greater than those of interest for regulatory purposes (i.e., for doses orders of magnitude greater than current and possible revised iAs standards), we still present results for those models and consider their implications for sensitivity analysis.

Moreover, partly in order to compensate for the high-dose behavior just described, the double Hill models included a hierarchical structure for both v_1_ and v_2_. The study-specific v_1_ and v_2_ values varied around the pooled v_1_ and v_2_ values (the means of the study-specific distribution) according to a normal distribution with a standard deviation that had a prior distribution that was half-Cauchy (0,5), restricted to positive values. Note that even though the pooled v1 was constrained to be positive and the pooled v_2_ was constrained to be negative, the study-specific values were not so constrained. So, while the overall (pooled) behavior ascribed by the double Hill model would have a positive term and a negative term (allowing for nonmonotonicity), that need not be the case for any individual study. This is analogous to the treatment of the b parameters (dose coefficients) in the simple linear logistic model, i.e., the pooled b parameter was constrained to be positive (because the a priori evidence suggested that arsenic does increase bladder cancer risks rather than decrease them), but the study-specific values for the coefficient were allowed to be positive or negative.

For the bladder cancer meta-analysis data set under consideration, which has 12 studies, there were 16 nominal parameters for the fractional polynomial models. Because the double Hill models were hierarchical with respect to two parameters, the nominal number of parameters was nearly doubled, to 31. Both counts include a parameter defining the mean of the Poisson random variable for the expected number in the reference group of the sole cohort study in the data set (Chen et al., 2010b). For comparison, the simple linear logistic model had 15 nominal parameters: a single mean dose coefficient, the 12 study-specific coefficients, and a standard deviation defining the variability of those hierarchical coefficients around the mean value, as well as the Poisson mean for the expected number in the cohort study reference group. The number of parameters in the models is important for model comparison and selection.

The MCMC simulations were run using RStan (version 2.21.0) running under R (version 4.0.2). Convergence was checked by monitoring the reported Rhat values (values less than 1.01 for each parameter) and effective sample sizes. Instances of divergent iterations were noted but the frequencies of divergences were less than 0.1% (a rule of thumb adopted for accepting the results, based on guidance supplied by Stan developers)^23^ unless otherwise noted. For each variation of the fractional polynomial models, 20,000 post-warm-up draws were obtained (5,000 in each of 4 chains). For the 4 double Hill models, 200,000 post-warm-up draws were obtained (50,000 from each of 4 chains).

##### Results

The Bayesian analysis used for these investigations is a likelihood-based approach. In particular, it is based on the posterior likelihoods associated with the range of parameter values, given the data and the prior likelihood of those parameters.

One perspective for model selection (or model averaging) would focus on the maximum posterior likelihood that can be obtained across all parameter values. Such a view is analogous to a maximum likelihood perspective for frequentist analyses—a model that provides a greater maximum (posterior) likelihood is preferred over a model that can only achieve a maximum that is less than the first model. In the present analyses, we have characterized that maximum in two ways. First, we have computed the maximum log-posterior (labeled “lp__” in Stan and referred to as “lp” here) from among the parameter samples obtained in the MCMC draws. Second, we have estimated the density of lp using a kernel estimation technique, and reported the maximum estimated by that procedure. The following plot (Figure C-6) shows the relationship between those two metrics over the suite of models under investigation.

Figure C-6 Sample maximum lp vs. estimated maximum lp

Note that these two metrics are co-linear; they are obviously closely related, and either would give the same ranking of the models. We focus therefore on the sample maximum lp.

Another perspective on model comparison is to focus on the average fit, over the range of parameter values represented in the posterior sample. Such a metric recognizes that the Bayesian approach does not concentrate on the maximum likelihood, but rather on the variability of the values that are most consistent with the observations; it is a distributional approach and therefore does not focus merely on the single best parameter set. Given that perspective, it is more natural to focus on a value that better represents that distribution. We have chosen the sample mean lp for that representation. The following plot (Figure C-7) shows the relationship between the sample maximum and the sample mean lp:

Figure C-7 Sample maximum lp vs. sample mean lp

The relationship here is not as linear as that between the estimates of the maximum lp. In fact, depending on the choice of metric, one of two fractional polynomial models could be identified as best.

Table C-18 gives the values for all three metrics under consideration, and it highlights those two fractional polynomial models (color coded to associate the model with the basis for selecting it). In fact, if one were to weight the fractional polynomial models on the basis of the maximum or mean lp values, then one or the other of these two models would receive more than 99.5% of the weight—i.e., the other fractional polynomial models would contribute essentially nothing to estimates of quantities of interest.^24^

Table C-18 Table of models with results relevant to model selection

Class | Subset^a^ | Specification | | No. of parameters | Estimated max lp (Kernel Density) | Max sample lp | Mean sample lp
Class | Subset^a^ | p1 | p2 | No. of parameters | Estimated max lp (Kernel Density) | Max sample lp | Mean sample lp
Fractional Polynomial | Set A (p1 > p2; neither = 0) | –1 | −2 | 16 | −8,937 | −8,939.5 | −8,958.2
| | –0.5 | −2 | 16 | −8,921 | −8,922.8 | −8,941.3
| | −0.5 | −1 | 16 | −8,934 | −8,936.2 | −8,954.2
| | 0.5 | −2 | 16 | −8,892 | −8,894.3 | −8,931.6
| | 0.5 | −1 | 16 | −8,929 | −8,931.3 | −8,949.1
| | 0.5 | −0.5 | 16 | −8,938 | −8,939.8 | −8,956.1
| | 1 | −2 | 16 | −8,922 | −8,924.1 | −8,941
| | 1 | −1 | 16 | −8,935 | −8,936.7 | −8,953.8
| | 1 | −0.5 | 16 | −8,942 | −8,944.2 | −8,960.4
| | 1 | 0.5 | 16 | −8,942 | −8,943.8 | −8,960.4
| | 2 | −2 | 16 | −8,936 | −8,937.6 | −8,956.2
| | 2 | −1 | 16 | −8,945 | −8,946.8 | −8,964.1
| | 2 | −0.5 | 16 | −8,947 | −8,949.0 | −8,966.6
| | 2 | 0.5 | 16 | −8,942 | −8,944.4 | −8,963.7
| | 2 | 1 | 16 | −8,941 | −8,943.3 | −8,961
| | 3 | −2 | 16 | −8,948 | −8,950.0 | −8,968.4
| | 3 | −1 | 16 | −8,952 | −8,953.8 | −8,970
| | 3 | −0.5 | 16 | −8,950 | −8,952.5 | −8,970.6
| | 3 | 0.5 | 16 | −8,946 | −8,947.7 | −8,966.6
| | 3 | 1 | 16 | −8,944 | −8,946.3 | −8,963.9
| | 3 | 2 | 16 | −8,943 | −8,945.5 | −8,963.7
| Set B (p2 = 0) | −2 | 0 | 16 | −8,903 | −8,905.8 | −8,926.2
| | −1 | 0 | 16 | −8,930 | −8,932.2 | −8,950.2
| | −0.5 | 0 | 16 | −8,937 | −8,939.4 | −8,956
| | 0.5 | 0 | 16 | −8,931 | −8,933.3 | −8,948.3
| | 1 | 0 | 16 | −8,933 | −8,935.1 | −8,951.7
| | 2 | 0 | 16 | −8,937 | −8,939.0 | −8,955.6
| | 3 | 0 | 16 | −8,939 | −8,941.6 | −8,958.8
| Set C ((p1 = p2) | −2 | −2 | 16 | −8,956 | −8,957.6 | −8,976.8
| | −1 | −1 | 16 | −8,942 | −8,943.9 | −8,961.3
| | −0.5 | −0.5 | 16 | −8,941 | −8,942.8 | −8,959.7
| | 0.5 | 0.5 | 16 | −8,940 | −8,942.2 | −8,959.6
| | 1 | 1 | 16 | −8,940 | −8,942.4 | −8,958.7
| | 2 | 2 | 16 | −8,941 | −8,943.6 | −8,961.6
| | 3 | 3 | 16 | −8,943 | −8,944.9 | −8,963.1
Double Hill | | 1 | 1 | 31 | −8,925 | −8,926.5 | −8,949.4
| | 1 | 2 | 31 | −8,926 | −8,927.9 | −8,949.9
| | 2 | 1 | 31 | −8,928 | −8,929.8 | −8,953.2
| | 2 | 2 | 31 | −8,931 | −8,932.3 | −8,953.6

a Fractional polynomial sets are characterized as follows. Set A models do not include any ln(d) terms, just two terms having d^p1^ and d^p2^. Set B includes one ln(d) term, and one terms of the form d^p1^. Set C models include a term of the form d^p1^ and a term of the form dp1*ln(d).

Interestingly, the two highlighted models have a d−2 term that is a significant contributor only at low doses (increasing risk at doses less than 1 with greatest impact as dose decreases toward zero) and a term that is concave down (becomes less steep as dose increases, i.e., sqrt(d) and ln(d)) so that the change in risk with increasing dose flattens out to some degree at higher doses. The graphs of the associated odds ratios are shown in the following plots (Figures C-8 and C-9), using mean values of the posterior distributions of the relevant parameters for those plots.

Figure C-8 Dose-response for fractional polynomial model with p1 = 0.5 and p2 = 2

Figure C-9 Dose-response for fractional polynomial model with p1 = −2 and p2 = 0

The only non-monotonicity evident occurs at doses lower than the reference dose of 0.071 μg/kg-day, the background iAs exposure for the target U.S. population. In other words, these best fractional polynomial models predict no deceases in risk associated with increasing dose for any levels of exposure at or above the current background exposure level. Note that the best fitting fractional polynomial models presented in Figures C-8 and C-9 also showed a linear or concave down dose response relationship throughout the range of the data fit. Also, unlike the logistic power models used in this assessment, these models did not show an upward curvature up through doses with high estimated odds ratios. However, the upward slope near zero indicates that models of this form should not be extrapolated to very low sub-background doses.

In the above discussion, we have focused solely on the fractional polynomial model results. The reason for that is because the double Hill models are not competitive with the fractional polynomial models when number of parameters are factored into the consideration. Note from the figures above that the lp values of the double Hill models are in the middle of the range of the fractional polynomial models. But when one considers that the double Hill models have (nominally) 15 additional parameters, it is evident that the added complexity of the double Hill models is not warranted. From a Bayesian Information Criterion (BIC) perspective, whether applied to the maximum or the mean lp values, the double Hill models would be ruled out of consideration.

More generally, if one were to use a BIC approach to identify models that would be preferred over the simple linear logistic model, none of the double Hill models would be preferred. Of the fractional polynomial models, the following versions would be preferred.^25^

Table C-19 Fractional polynomial models referred by BIC to linear model

Specification
p1 | p2
−0.5 | −2
0.5 | −2
0.5 | −1
1 | −2
−2 | 0
−1 | 0
0.5 | 0
1 | 0

The shading in Table C-19 identifies again the two models that are clearly superior to all the others. The listing in Table C-19 is based on mean lp; if maximum lp were considered then the last model version (1 0) would not be considered to be preferred to the linear model.

For that subset of fractional polynomial models, Table C-20 presents the predicted extra lifetime risks at a series of doses selected as being potentially relevant to regulatory decision making. The order of the fractional polynomial models is from greatest mean lp to least mean lp.

Table C-20 Mean lifetime extra risk at various doses, using 0.071 μg/kg-day as the reference

Model | Doses (μg/kg-d)
Model | 0.0071 | 0.05 | 0.12 | 0.19 | 0.26 | 0.33 | 0.75 | 1.45
Linear | −0.00032 | −0.00011 | 0.00025 | 0.00061 | 0.00097 | 0.0013 | 0.0037 | 0.0083
−2, 0 | −0.014 | −0.0034 | 0.0065 | 0.014 | 0.020 | 0.026 | 0.051 | 0.080
0.5, −2 | −0.0022 | −0.00055 | 0.0011 | 0.0023 | 0.0034 | 0.0045 | 0.00961 | 0.017
1, −2 | −0.00017 | −0.000056 | 0.00013 | 0.00032 | 0.00051 | 0.00070 | 0.0019 | 0.0040
−0.5, −2 | −0.019 | −0.0098 | 0.026 | 0.061 | 0.091 | 0.12 | 0.21 | 0.28
0.5, 0 | −0.0024 | −0.00056 | 0.0010 | 0.0022 | 0.0032 | 0.0041 | 0.0082 | 0.014
0.5, −1 | −0.0018 | −0.00050 | 0.00097 | 0.0021 | 0.0031 | 0.0040 | 0.0087 | 0.015
−1, 0 | −0.013 | −0.0033 | 0.0064 | 0.014 | 0.020 | 0.026 | 0.053 | 0.084
1, 0 | −0.0034 | −0.00062 | 0.0010 | 0.0020 | 0.0028 | 0.0035 | 0.0061 | 0.0091

For all the models listed in Table C-20, the extra lifetime risk increases monotonically as dose increases. There is no evidence of non-monotonicity within the range of doses displayed, which includes a dose 10 times less than the estimated average background exposure in the U.S. and extends up to roughly 20 times that exposure level.

For the two fractional polynomial models that were clearly superior to the others with respect to model fit, the extra risks for doses greater than the average background dose are uniformly greater than the corresponding risk estimates from the linear model. The difference is reduced at the high end of the displayed dose range. This reflects the steeper dose-response shape for models that have ln(d) and sqrt(d) terms which, as noted above will be steeper in the lower dose range and then less steep at higher doses. In contrast, the linear model will have the same slope throughout the entire dose range.

##### Summary

This analysis examined a large collection of alternative models, within the logistic model umbrella, which are more flexible with respect to curve shape. In particular, two sets of models, totaling 39 models in all, were defined in such a way so as to allow for non-monotonic, threshold-like, and also concave-down (plateauing) dose-response shapes. This in contrast to the simple logistic model, which, though based on concepts of a distribution of thresholds in a population (Prentice, 1976), does not ever assume a non-monotonic shape nor allow concave-down behavior.

Not all of the alternative models are biologically or toxicologically realistic. In particular, several of the models within the fractional polynomial family lead to the highly unrealistic behavior that the odds of disease increase to infinity as dose gets close to zero. Selection of suitable priors for the parameters of the model, within the range of doses that might be relevant to setting iAs standards, attempted to ameliorate the effect of this behavior. This modeling indicated that forms that were monotonic within the range of fitting and showed linear and/or concave-down dose response relationships at moderate doses had improved measures of fit for the bladder cancer data. However, this modeling process was complicated, required care to avoid biologically implausible behaviors, and should not be extrapolated to very low sub-background doses. Such an approach was judged to be less useful for practical risk assessment of iAs for the multiple endpoints considered in this assessment, As it happens, two of the fractional polynomial models applied to the bladder cancer data set would indeed be selected, on the basis of AIC or BIC comparisons alone, over the simple logistic model (see Figures C-6 and C-7 and Tables C-18 and C-19).^26^, However, EPA believes that these results provide a useful sensitivity analysis showing alternative statistical fits to the bladder cancer data. Note that both yielded risk estimates (lifetime extra risk) that are greater than those predicted by the simple logistic model.

EPA also notes that it took a more straight-forward approach to modeling to address the possibility of threshold, or threshold-like, behavior within the logistic model framework. That approach now constitutes the primary analysis approach, i.e., application of the logistic-power model. As shown in Figure C-10, increasing values of the power parameter flatten out the low-dose dose-response behavior, extending the range of doses for which the probability of response is essentially the same as the probability of response at 0 dose. While this model does not allow non-monotonicity of response, EPA considers it a better approach for exploring and incorporating the possibility of a threshold. On the other hand, the logistic power modeling approach used in the assessment does not allow fitting of dose-response relationships that show a concave-down relationship at moderate doses. Such model shapes, as illustrated in this bladder cancer sensitivity analysis can lead to increased estimates of risk at prevalent exposures.

Figure C-10 Dose-response for the logistic-power model with varying values of the power parameter

### C.1.2 Bayesian Dose-Response Meta-Analysis Results

#### Bladder Cancer

##### Extrapolation of bladder cancer extra risk to target U.S. population

Table C-21 Lifetable rates for all-cause mortality and bladder cancer mortality and incidence

Age range | All-cause mortality rates (per 100,000)^a^ | Bladder cancer mortality rates (per 100,000)^b^ | Bladder cancer incidence rates (per 100,000)^b^
0–1 | 567 | 0 | 0
1–4 | 24.3 | 0 | 0
5–9 | 11.6 | 0 | 0
10–14 | 15.5 | 0 | 0
15–19 | 51.5 | 0 | 0.1
20–24 | 95.6 | 0 | 0.2
25–29 | 121 | 0 | 0.4
30–34 | 145.4 | 0 | 0.7
35–39 | 173.8 | 0.1 | 1.4
40–44 | 218.4 | 0.3 | 2.7
45–49 | 313.2 | 0.6 | 6
50–54 | 488 | 1.4 | 12.6
55–59 | 736.5 | 3.2 | 23.8
60–64 | 1,050.2 | 5.8 | 41.5
65–69 | 1,473.5 | 9.5 | 68.6
70–74 | 2,206.9 | 16.7 | 100.2
75–79 | 3,517.8 | 27 | 135.4
80–84 | 5,871.7 | 47.8 | 165.2

a National Vital Statistics Report, Volume 68, Number 9, 2/16/2016. Final data for 2017: https://www.cdc.gov/nchs/data/nvsr/nvsr68/nvsr68_09-508.pdf.

b SEER cancer statistics for 2017: https://gis.cdc.gov/Cancer/USCS/DataViz.html.

##### Bladder cancer study and dataset selection

Table C-22 describes the studies selected for the bladder cancer Bayesian dose-response meta-analysis.

Table C-22 Data sets selected for bladder cancer Bayesian dose-response meta-analysis

Study/Meta-regression Dataset | Study design | Location | Exposure/dose metric | Estimate of iAs exposure group mean µg/kg-d daily intake range (Estimate of mean U.S. equivalent µg/L drinking water range)^a^ | Health outcome/endpoint | Description | Limitations
Baris et al. (2016); Table 3, Cumulative arsenic intake, mg, Unlagged | Case-control | United States (New England) | Cumulatrive arsenic intake (mg) | 0.1–0.44; (7.3–38) | Histologically confirmed carcinoma of the urinary bladder (Including carcinoma in situ) | Very large case-control study (1,213 cases, 1,418 controls) of U.S. population exposed to low arsenic concentrations in drinking water. Substantial details on residential and occupational histories, and demographic and personal information. Lifetime residential and water consumption histories used to estimate daily and cumulative intake and control for key covariates | Potential for exposure misclassification exists due to very low iAs concentrations and multiple methods employed (i.e., a mix of measurements, models, and predictions based on the use of public water supplies and “deep or dug” private wells).
Bates et al. (1995); Table 3, Cumulative dose (mg), All Subjects | Case-control | United States (Utah) | Cumulative As intake (water) | 0.12–0.15; (9.09–11.8) | Histologically confirmed bladder cancer | Moderate size case-control study (117 cases, 266 controls) of U.S. population exposed to low-moderate arsenic concentrations in drinking water. Lifetime residential and water consumption histories were used to derive cumulative intake estimates; separate analyses were conducted for smokers | Exposure estimates were based on As measurements from municipal water supplies, which were assumed to be representative of individual exposures and stable over time.
Bates et al. (2004); Table 2, Arsenic (μg/liter), Model 1: Excluding proxy wells | Case-control | Argentina | Drinking water As conc. | 0.56–8.2; (49.1–743.6) | Transitional bladder-cell cancer cases identified by pathologists and urologists in the study area | Moderate size case-control study (114 matched case-control pairs) over a wide exposure range; current and past water concentrations measured, the analysis controlled for major covariates, drinking water consumption, and duration of well use; examined risks versus exposure “time windows” | There were relatively few cases and controls in the higher water concentration strata; exposure estimates depend on relative contributions from well/spring versus public water supplies, for which As concentrations were very different
Chang et al. (2016); Table 3, As (continuous) Adjusted OR | Case-control | Midwest Taiwan | Urinary As excretion (μg/liter) | 1.1–5.3; (98.2–480) | Urothelial carcinomas identified by urologists and pathologically confirmed | Moderate size case-control study (205 cases, 406 controls) recruited from China Medical University; Hospital, Taichung, Taiwan, between June 2011 and December 2013. Urinary As dose metric; estimated As intakes near typical U.S. values; multiple studies have addressed effects of nutrition, methylation profiles, genetic variants on As-associated bladder cancer risks in subsets of the same cohort. Trend tests suggest iAs poses a moderate UC risk (0.05 < p < 0.1) relative to risk of UC from increased urinary levels of cadmium, chromium, nickel, and lead (p < 0.05). | Hospital-based referent population somewhat dissimilar with regard to several covariates from exposed groups; lack of data on historical exposures. Nutritional status of the cohort is not specified, but they are not likely to be malnourished like the SE Taiwan “endemic” area
Chen et al. (2010b); Table 3, Cumulative arsenic exposure (μg/L y), All urinary cancer | Prosp. Cohort | NE Taiwan | Cumulative As exposure (water) | 0.83–16.44; (73.6–1492) | Urinary cancers identified in Taiwan national cancer.; Registry: includes ICD-9 defined bladder (code 188), kidney (Code 189.0), and others (code 189.1–189.9) | Very large cohort study (6,888 subjects with exposure measurements), individual well As levels measured for 85% of subjects. Broad exposure range, well-documented case ascertainment, good follow-up (12 yr), controlled for major covariates. Follow-up study subsequently conducted on the same cohort (Yang et al., 2013). | Relatively small numbers of cases in some exposure strata
Meliker et al. (2010); Table 3, µg/day (TWA), Multivariate-adjusted analyses | Case-control | United States (Michigan) | Daily As intake (water) | 0.1–0.45; (7.3–39.1) | Bladder cancer cases identified by the Michigan Cancer Surveillance Program (the state cancer registry) | Large (411 cases, 566 controls) study of U.S. population exposed to mostly low levels or arsenic in water. Lifetime residential, water use, and occupational/lifestyle histories were used to calculate average daily As intake, and control for covariates. Separate analyses for smokers, non-smokers | Reliance on geostatistical model for exposure estimates; narrow exposure range, particularly for public systems; possible case selection bias (~25% of eligible cases participated)
Steinmaus et al. (2003); Table 3, Cumulative Exposure, 5-year lag (mg) | Case-control | United States (CA, NV) | Cumulative As intake (water) | 0.1–0.23; (7.3–19.1) | Bladder cancer cases identified in Nevada. Cancer Registry and the Cancer Registry of Central California | Moderate size (181 cases, 328 controls) study of U.S. population exposed to low-moderate levels of As in drinking water. Lifetime residential and water consumption profiles, along with a large database of As levels in public and private water sources, were used to estimate lifetime intake. Controlled for important covariates | Small numbers/proportions of controls, cases in higher exposure strata; unclear if effects of changing water As levels were adequately addressed
Steinmaus et al. (2013); Table 3, Lifetime daily average: all yrs ((μg/d), high dose dropped | Case-control | N. Chile | Lifetime avg. daily As intake (water) | 1.26–10.76; (112.7–976) | Histologically (98%) or radiologically/clinically (2%) confirmed cases of bladder cancer | Large case-control study (232 cases, 640 controls), well-documented historical water As exposures, good resolution in low-moderate exposure range. Residential and water use histories are used to estimate As intakes. The subject cohort has been the subject of a number of studies of As-related cancer and covariate interactions | Relied on municipal water As measurements for exposure estimates, but unique characteristics of study area (lack of alternative sources), suggest this is not a major source of uncertainty
Wu et al. (2013); Table 2, Total arsenic, Multivariate adjusted OR (μg/g creatinine) | Case-control | NE Taiwan | Urinary As excretion | 0.127–0.566; (9.7–49.6) | Urothelial Carcinomas diagnosed by Taipei Medical University Hospital Department of Urology | Large case-control study (300 cases, 594 controls) in well-studied cohort (National Taiwan University Hospital, Taipei Medical University Hospital and Taipei Municipal Wan Fang Hospital); recruited between September 2002 and May 2009 from. Urinary As dose metric; estimated As intakes near typical U.S. values; multiple studies have addressed effects of nutrition, methylation profiles, genetic variants on As-associated bladder cancer risks in subsets of the same cohort. | Hospital-based referent population somewhat dissimilar with regard to several covariates from exposed groups; lack of data on historical exposures. Nutritional status of the cohort is not specified, but they are not likely to be malnourished like the SE Taiwan “endemic” area
Karagas et al. (2004); Table 2, Toenail arsenic Conc (mcg/g), All subjects | Case-control | United States (NH) | Toenail arsenic concentration | 0.116-0.154; (8.72–12.2) | | Large case-control study (383 cases, 641 controls) identified in the New Hampshire Cancer Registry from July 1994–June 1998. Toenail arsenic concentration. Important confounders (age, sex, smoking, etc.) controlled for. | Study reported to have limited statistical precision. Misclassification (especially in the lower range of the exposure range) may have limited the ability to observe the shape of the dose-response.
Michaud et al. (2004); Table 2, Quartile range (μg/g) | Case-control | SW Finland | Toenail arsenic concentration | 0.108-0.165; (8–13.2) | Histologically confirmed cases of incident bladder cancer identified through the Finnish Cancer Register, Hospital Discharge Registry, and death certificates | Moderately sized case-control study (280 cases, 293 controls) using records from population based randomized trial of male smokers (initiated from 1985-1988, followed until 1998) and supplemented afterwards with records from two Finnish national registries and death certificates. Toenail arsenic metric. Important confounders (smoking duration, education, etc.) controlled for. | Original clinical trial population was in male smokers, so generalizability to women or non-smokers may be limited; measurement error in toenail arsenic concentrations could have attenuated risks observed in study given possibility of increasing misclassification over time and latency period for bladder cancer

a The µg/kg-d ranges were obtained from MLE estimates reported in Table C-25; water concentrations were estimated assuming median U.S. dietary background of 0.02 µg/kg-d (Xue et al., 2010) and mean U.S. water consumption rate of 0.011 L/kg-d (U.S. EPA., 2019; Table 3-1, “All Ages”).

##### Comparison of studies selected for EPA dose-response meta-analysis and studies used in earlier meta-analyses

EPA found considerable overlap between the studies included in the current dose-response meta-analysis and those identified in earlier meta-analyses (see Table C-23). Of the 11 studies chosen by EPA, a core group of 5 studies were chosen for all (Meliker et al., 2010; Bates et al., 2004; Baris et al., 2016) or for all but 1 (Steinmaus et al., 2013; Chen et al., 2010b) of the meta-analyses published after them. Studies selected for the earlier meta-analysis that were not used in the EPA dose-response meta-analysis tended to be either (1) superseded by later analyses of the same cohorts, or (2) based on a dose metric that EPA decided not to be sufficiently reliable (toenail arsenic.) EPA judged that outcome measures for several of the other studies were not amenable to dose-response meta-analysis or that exposure measurements were too uncertain and the range of exposures too narrow.

Table C-23 Study selection for EPA bladder cancer dose-response meta-analysis compared to earlier meta-analyses

Study | EPA dose-response meta-analysis | Chu and Crawford-Brown (2006) | Begum et al. (2012) | Tsuji et al. (2014a) | Saint-Jacques et al. (2014) | Lynch et al. (2017b) | Shao et al. (2021)
Baris et al. (2016) | ✔ | | | | | ✔ | ✔
Bates et al. (1995) | ✔ | ✔ | ✔ | ✔
Bates et al. (2004) | ✔ | ✔ | ✔ | ✔ | ✔ | ✔ | ✔
Chang et al. (2016) | ✔
Chen et al. (2010b) | ✔ | | | ✔ | ✔ | ✔ | ✔
Chiou et al. (1995) | | ✔ | ✔ | | | ✔
Chiou et al. (2001) | | ✔ | ✔ | | ✔
Huang et al. (2008a) | | | | | ✔ | ✔
Karagas et al. (2004) ^a^ | ✔ | | ✔ | ✔ | | | ✔
Kurttio et al. (1999) | | ✔ | ✔ | ✔ | ✔ | ✔ | ✔
Lewis et al. (1999) | | | | ✔
Meliker et al. (2010) | ✔ | | ✔ | ✔ | ✔ | ✔ | ✔
Michaud et al. (2004) ^a^ | ✔ | | ✔ | ✔
Moore et al. (2003) | | ✔ | ✔
Mostafa and Cherry (2015) | | | | | | ✔ | ✔
Steinmaus et al. (2003) | ✔ | ✔ | ✔ | ✔
Steinmaus et al. (2013) | ✔ | | | | ✔ | ✔ | ✔
Wang et al. (2009) | | | | | | ✔
Wu et al. (2013) | ✔

a Toenail iAs study.

Chiou et al. (1995) and Huang et al. (2008a) were included in Lynch et al. (2017b), Chu and Crawford-Brown (2006), Begum et al. (2012), and Saint-Jacques et al. (2014) meta-analyses; EPA chose not to use data from these studies because they were based in the southwest Taiwan “endemic” area. Exposure level estimates were extremely uncertain and generally quite high, and the incidence of Blackfoot Disease and potential poor nutrition in the study subjects led EPA not to include data from this region.

Kurttio et al. (1999) was included in all six of the previous meta-analyses. While this study provides some evidence supporting exposure-response for bladder cancer at low water concentrations particularly among smokers, the range of exposures was extremely low with exposure groups of <0.1, 0.1–0.5, and > 0.5 µg/L. EPA judged that exposure uncertainties were likely large compared to the within-stratum variation, and the potential for exposure group misclassification was too high to warrant inclusion in its meta-analysis.

Chiou et al. (2001) was used by Chu and Crawford-Brown (2006), Begum et al. (2012), and Saint-Jacques et al. (2014) in their meta-analyses. EPA did not include outcome data from this study (although exposure statistics were used), because a later study (Chen et al., 2010b) reported urinary cancer risks in this cohorts after a longer follow-up period.

Moore et al. (2003) was also used as a source of data in the two older meta-analyses. EPA did not select data from this study because only raw counts and relative risks not adjusted for covariates were provided. Thus, there was no way to calculate adjusted counts for the dose-response meta-analysis.

Data from Lewis et al. (1999) was selected for meta-analysis by Tsuji et al. (2014a). EPA chose not to include this study because it was judged that exposure uncertainty was unacceptable large, and the study reported SMRs for bladder cancer in three exposure groups on the basis of only three deaths in males and two deaths in females.

Data from Mostafa and Cherry (2015) was selected for meta-analysis by Lynch et al. (2017b) and Shao et al. (2021). EPA chose not to include this study because it was judged that exposure uncertainty was unacceptably large. The authors associated responses with mean well concentrations within Bangladesh regions called “thana.” The 9,870 subjects of the study came from 360 thana. For each individual of a thana, exposure to arsenic in drinking water was estimated as the mean arsenic concentration of multiple wells (1–16) within the thana in which the patient lived at the time of biopsy.

Finally, due in part to the availability of the El-Masri-Kenyon iAs PBPK model (El-Masri et al., 2018a, b), EPA included two recent urine biomarker studies (Wu et al., 2013; Chang et al., 2016) that were not included in any of the previous meta-analysis. These studies were not available at the time most of these authors began their literature reviews and were explicitly excluded from the Saint-Jacques et al. (2014), Lynch et al. (2017b) and Shao et al. (2021) meta-analyses.

While there are differences in the modeling approaches used by EPA and earlier meta-analyses, differing results can be attributed largely to study and data selection. For instance, while the Lynch et al. (2017b) approach differed from EPA’s approach with respect to the exposure metric modeled and the lifetime adjustment method used, when the Lynch et al. (2017b) dataset was evaluated by both approaches, the bladder cancer extra risk predictions were nearly identical, with the EPA approach predicting a linear slope of 0.0009 (µg/kg-day)⁻^1^ and the Lynch et al. (2017b) approach predicting a linear slope of 0.0008 (µg/kg-day)⁻^1^ (see Figure C-11).

Figure C-11 Relationship between dose (µg/kg-day) and mean extra risk (ER) predicted by EPA approach using EPA data, EPA approach using Lynch et al. (2017b) data and Lynch approach using Lynch et al. (2017b) data

Study differences are also at least partially explanatory with respect to differences between the current EPA Bayesian dose-response meta-analysis results for bladder cancer and the results reported in Shao et al. (2021). The study authors in Shao et al. (2021) preferentially used drinking water studies. The specific dose metrics also play a part in differences between analyses, with Shao et al. (2021) modeling study results presented for µg/L and EPA instead choosing, in some cases, dose-metrics judged to be more suitable for accurately describing the dose response. An example of this is seen for the Baris et al. (2016) study: EPA used the unlagged cumulative dose metric whereas Shao et al. (2021) used the unlagged drinking water dose metric. Unless a population is limited in its source of fluids (e.g., populations that rely almost exclusively on a single well-water source), it is extremely important to survey individuals as to their consumption habits to approximate their actual iAs dose from the water source of interest. Baris et al. (2016) made a particular point of this, noting that “The contrast in our findings for cumulative arsenic intake and average arsenic concentration underscores the importance of incorporating water intake when estimating an individual’s total arsenic exposure in low to moderately exposed populations such as that in northern New England.” Shao et al. (2021) also completely ignores the role that dietary exposure has in iAs-induced disease. Differences in dietary exposure to iAs is reasonably assumed across divergent study populations, and thus not taking this into account ignores an important, and differential, source of exposure. EPA’s dose-conversions explicitly takes population-specific dietary exposures into account when calculating the daily intake dose-metric.

In addition to study selection and the dose-metrics modeled, the specific methodology employed by Shao et al. (2021) also directly results in the observed differences between their results and EPA results. In brief, Shao et al. (2021) base their analysis on model fits using a Hill model, based on a claim that the Hill model has the greatest flexibility to model different shapes of dose-responses. The authors also state that the Hill model “may plausibly describe underlying biological processes” but are silent on the biological processes that the model ostensibly describes. Importantly, the Hill model has questionable features for use in cancer risk assessment. In particular, the Hill model formula implies that any upward curvature that may be indicated at high doses, is necessarily also present at low doses. In particular, a Hill model fit showing any high dose upward curvature precludes the presence of any linearity of response at low dose. On the contrary, models that allow a degree of low dose linearity—even in the presence of differing patterns of high-dose response—have long been used in developing health protective cancer risk assessments.

Shao et al. (2021) also defend an application of a partially hierarchical Hill model such that, among the 4 model parameters, would only allow for population differences for the “a” (response as zero exposure) and “b” (sensitivity of individuals to iAs exposure) parameters. They state that these parameters “are the most important factors of variability in populations at low exposures” and that parameters “c” (dose at half-maximal response) and “g” (threshold parameter) are “more affected by data points in [the] high exposure range.” The paper states that use of partially hierarchical model “will avoid introducing unnecessary uncertainty.” However, the characterization of the “c” and “g” parameters as important at high, but not low dose is not appropriate. The “c” parameter is the dose at half-maximal response and essentially defines the point of transition between low and high dose data. Then, the “g” parameter defines the steepness of the dose response, which in the Hill model applies to both high and low dose response. Arguably, fully addressing “c” and “g” parameters is the most needed feature in this modeling as these models determine the claimed threshold behavior of modeling in this paper. Omission of these parameters in hierarchical modeling implies that all populations are expected to have the same “threshold,” which ignores population-specific characteristic such as genetic polymorphisms, dietary exposure, and other risk factors that impact disease risk due to iAs exposure. Lastly, having the “a” parameter be hierarchical is somewhat confusing as, by definition RR equals 1 at the reference dose, so all populations should have the same response at their respective background exposure level.

While the authors do implement a fully hierarchical model for some calculations, insufficient information is given to judge these modeling results. The main paper reports the BMDL-BMDU confidence interval for partially hierarchical modeling results, but the supplemental material on the fully hierarchical model omits this information. Therefore, the claim that the partially hierarchical model “will avoid introducing unnecessary uncertainty” is unverifiable in that the confidence intervals between the two model approaches cannot be compared. This is potentially quite impactful as Shao et al. (2021) report that the BMD for bladder cancer from the fully hierarchical model (16.46 µg/L) is approximately 3 times lower than the BMD from the partially hierarchical model (52.35 µg/L). And, indeed, their BMD value for the fully hierarchical model seems entirely inconsistent with fitted partially hierarchal model and confidence limits shown in Figure 2 of the paper, where a very specific “jump” in both the MLE and confidence limits are shown near the estimated BMD value. An earlier paper (Shao et al., 2017) had concluded that a partially hierarchical model is sufficient in most cases and provide a set of simulations in which partially hierarchical and fully hierarchical models produced similar results in some relatively data rich situations. However, the simulations in Shao et al. (2021) indicate that this is not the case for the iAs bladder cancer studies given the factor of 3 difference between the BMD values estimated by the partially and fully hierarchical models.

EPA also questions the choice of some of the model parameters in the partially hierarchical model. First, the prior on the “g” parameter (threshold) is Uniform (0,50), meaning a uniform distribution where all values between 0 and 50 are equally likely. At first glance, this prior sounds “diffuse” or “uninformative” and implies that the data themselves will influence the modeling results. However, this prior actually provides a very heavy weighting towards dose-response curves that are highly threshold in nature (even step-like). In fact, approximately 96% of the prior weight on this parameter is on “g” values >2 which would imply steeply upward curving or threshold-like behavior. It is not desirable—especially for a health protective assessment—to place the dominant prior weight on threshold-like responses. There also seems to be an internal disagreement in the paper between the prior on the “c” parameter listed in Fig 1, Uniform (0,10), and the results of the modeling that show the half-maximal response dose at approximately 50 µg/L for bladder cancer and lung cancer and BMR = 1 relative deviation. Given a Uniform (0,10) prior, values for “c” close to 50 µg/L would never be possible.

##### Bladder cancer study-specific dose conversions

The study-specific dose conversions and confidence interval estimations were derived in Excel workbooks with the Yasai add-in for Monte Carlo simulations (http://www.yasai.rutgers.edu/). Each study required a potentially different set of assumptions for the dose conversions. The study-specific conversion assumptions and results are provided in the Excel files, which are included in the health outcome-specific intake uncertainty folders of the arsenic dose-response supplemental files (U.S. EPA, 2025), which are accompanied by an explanatory structured workflow, outline, and variable dictionary (U.S. EPA, 2024b). The following tables summarize the input equations and assumptions used in the Monte Carlo analyses (see Table C-24) and the MLE, low and high exposure and µg/kg-day dose estimates, as well as other input data (see Table C-25) for each of the studies used in EPA’s bladder cancer dose-response meta-analysis.

Table C-24 Exposure factors for converting study-specific dose-metrics into daily intake (µg/kg-day), bladder cancer studies^a^

Citation (country) | ADW E (yr) | AAD (yr) | LE, SD (μg/L) | WCR, SD (mL/kg-d) | BW, SD (kg) | DI, SD | H, SD (cm) | RD, SD (yr) | AGE, SD (yr) | Exposure or dose metric | Equation
Baris et al. (2016); (USA) | 65 | 65 | 2.5,3.3 | 10.7, 63 | 68,10 | 0.05, 0.09 | – | – | 65, 3.7 | mg, CE | Table C-2, Eq. A
Bates et al. (1995); (USA) | 34.4 | 66 | 2.5,3.3 | 10.7, 63 | 68, 10 | 0.05, 0.09 | – | – | 61.1, 13.1 | mg, CE | Table C-2, Eq. A
Bates et al. (2004); (Argentina) | 25.6 | 68.9 | 5,3.3 | 33.2, 15.7 | – | 0.1, 0.3 | – | – | – | μg/L, WE | Table C-2, Eq. D
Chang et al. (2016); (Taiwan) | – | – | – | – | 64.6, 6.4 | – | 164, 4.86 | – | 65.9, 10.52 | μg total As/g creat. | Table C-2, Eqs. F, G
Chen et al. (2010b); (NE Taiwan) | 42 | 65 | 5, 15 | 34.5, 23.2 | – | 0.65, 3.33 | – | 42, 15 | – | μg/L*yr, CE | Table C-2, Eq. E
Karagas et al. (2004); (USA) | 16.5 | 62.2 | 2.5, 3.3 | 10.7, 63 | | 0.05, 0.09 | | | | | Table C-2, Eqs. H, I, D
Michaud et al. (2004); (Finland) | 59.1 | 59.1 | 2.5, 3.3 | 10.7, 63 | | 0.05, 0.09 | | | | | Table C-2, Eqs. H, I, D
Meliker et al. (2010); (USA) | 66 | 66 | 2.5, 3.3 | 10.7, 63 | 68, 10 | 0.05, 0.09 | – | 66, 3.33 | – | μg/d, DD | Table C-2, Eq. B
Steinmaus et al. (2003); (USA) | 23.2 | 69.8 | 2.5, 3.3 | 10.7, 63 | 68, 10 | 0.05, 0.09 | – | – | 70.3, 9.6 | mg, CE | Table C-2, Eq. A
Steinmaus et al. (2013); (Chile) | 66 | 66 | 2.5, 3.3 | 1.7, 0.09 | 68, 10 | 1.0, 0.30 | – | – | – | μg/d, DD | Table C-2, Eq. C
Wu et al. (2013); (Taiwan) | – | – | – | – | 64.6, 6.4 | – | 164, 4.86 | – | 62.56, 13.5 | μg total As/g creat. | Table C-2, Eq. F, G

ADWE = average duration of well exposure; AAD = average age at diagnosis; LE = low (outside study) exposure; WCR = water consumption rate; BW = body weight; DI = dietary intake; H = height; RD = reported duration of well exposure; Age = control group average age.

a See Conversion Factor Validation spreadsheet for justifications for individual exposure factors.

Table C-25 Dose-response meta-analysis inputs and estimated effective counts for selected bladder cancer data sets, with three selected sets of dose values

Data set name (reported dose units) | Exposure ranges (in reported dose units) | Dose values for analysis (avg. daily μg/kg)^a^ | | | Raw counts | | | Adjusted OR/RR and 95% CIs | | | Effective counts^b^
Data set name (reported dose units) | Exposure ranges (in reported dose units) | MLE | Low | High | Cases | Controls | Expected | Adj OR | LCL | UCL | Cases | Controls | Expected
Chen et al. (2010b); (cohort study; cumulative water exposure, μg/L*yr)^c^ | <400 | 0.832 | 0.811 | 0.853 | 6 | – | 6.00 | 1 | 1 | 1 | 6.00 | – | 6.00
Chen et al. (2010b); (cohort study; cumulative water exposure, μg/L*yr)^c^ | 400–1,000 | 1.128 | 1.101 | 1.156 | 3 | – | 2.70 | 1.11 | 0.27 | 4.54 | 2.84 | – | 2.56
Chen et al. (2010b); (cohort study; cumulative water exposure, μg/L*yr)^c^ | 1,000–5,000 | 2.037 | 1.956 | 2.113 | 12 | – | 5.15 | 2.33 | 0.86 | 6.36 | 10.65 | – | 4.57
Chen et al. (2010b); (cohort study; cumulative water exposure, μg/L*yr)^c^ | 5,000–10,000 | 4.63 | 4.39 | 4.89 | 5 | – | 1.33 | 3.77 | 1.13 | 12.6 | 4.72 | – | 1.25
Chen et al. (2010b); (cohort study; cumulative water exposure, μg/L*yr)^c^ | >10,000 | 16.44 | 14.71 | 18.37 | 11 | – | 1.47 | 7.49 | 2.7 | 20.8 | 9.56 | – | 1.28
Steinmaus et al. (2013); (μg/d from water)^e^ | <41 | 1.26 | 1.23 | 1.29 | 32 | 197 | – | 1 | 1 | 1 | 32.00 | 80.25 | –
Steinmaus et al. (2013); (μg/d from water)^e^ | 41–136 | 1.99 | 1.93 | 2.05 | 39 | 194 | – | 1.08 | 0.62 | 1.87 | 40.18 | 93.31 | –
Steinmaus et al. (2013); (μg/d from water)^e^ | 137–307 | 3.55 | 3.42 | 3.67 | 64 | 154 | – | 3.06 | 1.75 | 5.35 | 59.12 | 48.45 | –
Steinmaus et al. (2013); (μg/d from water)^e^ | >307 | 10.76 | 8.43 | 14.52 | 97 | 95 | – | 5.85 | 3.41 | 10.05 | – | – | –
Wu et al. (2013); (μg/gm Creatinine) | ≤11.74 | 0.13 | 0.13 | 0.12 | 44 | 196 | – | 1 | 1 | 1 | 44.00 | 108.33 | –
Wu et al. (2013); (μg/gm Creatinine) | 11.74–20.94 | 0.25 | 0.25 | 0.25 | 63 | 196 | – | 1.42 | 0.9 | 2.25 | 69.52 | 120.54 | –
Wu et al. (2013); (μg/gm Creatinine) | >20.94 | 0.57 | 0.53 | 0.61 | 192 | 202 | – | 4.13 | 2.69 | 6.35 | 166.80 | 99.44 | –
Bates et al. (1995); (cumulative water iAs intake, mg) | <19 | 0.118 | 0.098 | 0.139 | 14 | 47 | – | 1 | 1 | 1 | 14.00 | 40.24 | –
Bates et al. (1995); (cumulative water iAs intake, mg) | 19–33 | 0.123 | 0.102 | 0.151 | 21 | 36 | – | 1.56 | 0.8 | 3.2 | 18.98 | 34.98 | –
Bates et al. (1995); (cumulative water iAs intake, mg) | 33–53 | 0.129 | 0.106 | 0.155 | 17 | 39 | – | 0.95 | 0.4 | 2 | 9.30 | 28.14 | –
Bates et al. (1995); (cumulative water iAs intake, mg) | ≥53 | 0.148 | 0.121 | 0.185 | 19 | 38 | – | 1.41 | 0.7 | 2.9 | 16.49 | 33.62 | –
Steinmaus et al. (2003); (cumulative Intake, mg) | <6.4 | 0.10 | 0.09 | 0.12 | 66 | 101 | – | 1 | 1 | 1 | 66.00 | 73.03 | –
Steinmaus et al. (2003); (cumulative Intake, mg) | 6.4–82.8 | 0.11 | 0.09 | 0.12 | 57 | 111 | – | 0.77 | 0.48 | 1.24 | 56.96 | 81.85 | –
Steinmaus et al. (2003); (cumulative Intake, mg) | >82.8 | 0.23 | 0.16 | 0.39 | 58 | 116 | – | 0.73 | 0.45 | 1.17 | 54.29 | 82.29 | –
Bates et al. (2004); (water concentration, μg/L) | 0–50 | 0.56 | 0.55 | 0.58 | 87 | 80 | – | 1 | 1 | 1 | 87.00 | 51.35 | –
Bates et al. (2004); (water concentration, μg/L) | 51–100 | 1.34 | 0.97 | 1.81 | 8 | 8 | – | 1.11 | 0.3 | 3.7 | 7.58 | 4.03 | –
Bates et al. (2004); (water concentration, μg/L) | 101–200 | 2.31 | 1.72 | 2.97 | 13 | 13 | – | 0.81 | 0.3 | 2 | 11.67 | 8.51 | –
Bates et al. (2004); (water concentration, μg/L) | >200 | 8.16 | 3.62 | 16.83 | 3 | 10 | – | 0.28 | 0.1 | 1.4 | 3.49 | 7.36 | –
Meliker et al. (2010); (water intake, μg/d) | <1 | 0.103 | 0.096 | 0.110 | 189 | 252 | – | 1 | 1 | 1 | 189.00 | 210.37 | –
Meliker et al. (2010); (water intake, μg/d) | 1–10 | 0.139 | 0.129 | 0.149 | 162 | 234 | – | 0.83 | 0.62 | 1.11 | 145.13 | 194.62 | –
Meliker et al. (2010); (water intake, μg/d) | >10 | 0.454 | 0.334 | 0.698 | 43 | 48 | – | 1.01 | 0.62 | 1.64 | 37.01 | 40.79 | –
Baris et al. (2016); (Cumulative arsenic intake, mg)^d^ | ≤15.7 | 0.103 | 0.096 | 0.109 | 244 | 327 | – | 1 | 1 | 1 | 244.00 | 220.70 | –
Baris et al. (2016); (Cumulative arsenic intake, mg)^d^ | >15.7–34.5 | 0.111 | 0.104 | 0.117 | 270 | 323 | – | 1.18 | 0.92 | 1.52 | 296.35 | 227.17 | –
Baris et al. (2016); (Cumulative arsenic intake, mg)^d^ | >34.5–77.0 | 0.127 | 0.119 | 0.135 | 292 | 324 | – | 1.13 | 0.88 | 1.46 | 279.40 | 223.65 | –
Baris et al. (2016); (Cumulative arsenic intake, mg)^d^ | >77.0–291.0 | 0.172 | 0.159 | 0.185 | 213 | 251 | – | 1.32 | 1 | 1.73 | 225.17 | 154.29 | –
Baris et al. (2016); (Cumulative arsenic intake, mg)^d^ | >291.0–483.6 | 0.29 | 0.25 | 0.34 | 28 | 33 | – | 1.3 | 0.74 | 2.28 | 33.04 | 22.99 | –
Baris et al. (2016); (Cumulative arsenic intake, mg)^d^ | >483.6 | 0.44 | 0.37 | 0.53 | 32 | 29 | – | 1.6 | 0.9 | 2.87 | 35.10 | 19.84 | –
Chang et al. (2016); (urinary μg/gm Creatinine) | [underlined: 6-46] | 1.09 | 1.04 | 1.14 | 59 | 137 | – | 1 | 1 | 1 | 59.00 | 91.93 | –
Chang et al. (2016); (urinary μg/gm Creatinine) | 46-86.8 | 2.29 | 2.22 | 2.36 | 58 | 134 | – | 0.94 | 0.59 | 1.5 | 55.60 | 92.17 | –
Chang et al. (2016); (urinary μg/gm Creatinine) | >86.8 | 5.32 | 4.98 | 5.67 | 88 | 135 | – | 1.52 | 0.98 | 2.37 | 86.18 | 88.34 | –
Karagas et al. (2004); (μg/gm toenail) | 0.009-0.06 | 0.116 | 0.102 | 0.137 | 90 | 162 | – | 1 | 1 | 1 | 90.00 | 131.95 | –
Karagas et al. (2004); (μg/gm toenail) | 0.06-0.09 | 0.120 | 0.103 | 0.144 | 119 | 162 | – | 1.37 | 0.96 | 1.96 | 133.74 | 143.12 | –
Karagas et al. (2004); (μg/gm toenail) | 0.09-0.13 | 0.122 | 0.106 | 0.146 | 88 | 157 | – | 1.08 | 0.74 | 1.58 | 92.61 | 125.71 | –
Karagas et al. (2004); (μg/gm toenail) | 0.13-0.19 | 0.127 | 0.105 | 0.160 | 48 | 96 | – | 1.04 | 0.66 | 1.63 | 49.54 | 69.84 | –
Karagas et al. (2004); (μg/gm toenail) | 0.19-0.28 | 0.137 | 0.099 | 0.210 | 21 | 32 | | 1.33 | 0.71 | 2.49 | 22.77 | 25.10
Karagas et al. (2004); (μg/gm toenail) | 0.28-0.33 | 0.142 | 0.114 | 0.188 | 3 | 13 | | 0.41 | 0.11 | 1.5 | 3.01 | 10.75
Karagas et al. (2004); (μg/gm toenail) | 0.33-2.48 | 0.154 | 0.119 | 0.214 | 14 | 19 | | 1.36 | 0.63 | 2.9 | 14.49 | 15.62
Michaud et al. (2004); (μg/gm toenail) | ≤9.71 | 0.11 | 0.09 | 0.13 | 65 | 74 | – | 1 | 1 | 1 | 65.00 | 115.53 | –
Michaud et al. (2004); (μg/gm toenail) | 9.71-17.98 | 0.12 | 0.10 | 0.15 | 71 | 3 | – | 1.09 | 0.68 | 1.74 | 48.29 | 78.75 | –
Michaud et al. (2004); (μg/gm toenail) | 17.98-30.51 | 0.13 | 0.11 | 0.17 | 73 | 73 | – | 1.13 | 0.71 | 1.8 | 50.68 | 79.71 | –
Michaud et al. (2004); (μg/gm toenail) | >30.51 | 0.17 | 0.12 | 0.24 | 71 | 73 | – | 1.13 | 0.7 | 1.81 | 47.15 | 74.16 | –

a Sets of dose values derived as per Allen et al. (2020a).

b Effective Counts derived as per Allen et al. (2020b).

c Person years of follow up for reference group = 29,599.

d Dose estimates and Ors are for cumulative intake (mg), unlagged.

e Effective counts shown are the ones used in the final dose-response meta-analysis based on dropping the high dose to improve model fit at low doses.

##### Summary of bladder cancer dose-response meta-analysis results for MLE dose estimates

The settings for the Bayesian dose-response meta-analysis summarized in Table C-26 were:

- 4 chains, each with iterations = 50,000; warmup = 37,500; thin = 1; Adapt_Delta^27^ = 0.99999
- post-warmup draws per chain = 12,500, total post-warmup draws = 50,000
- β_mean Gamma parameters: a = 0.52 and b = 1.12

This section provides details of the results for the hierarchical dose-response meta-analysis modeling (Table C-26, Figures C-12, and C-15), as well as dose-response plots from non-hierarchical modeling of individual studies (Figures C-13 and C-14). Additional details regarding the hierarchical and non-hierarchical modeling results can be obtained from the arsenic dose-response supplemental files (U.S. EPA, 2025), which are accompanied by an explanatory structured workflow, outline, and variable dictionary (U.S. EPA, 2024b).

Table C-26 Summary of bladder cancer Bayesian analysis output using MLE dose estimates

Study | Parameter^a^ | Mean | Standard error of mean | Standard deviation | 2.50% | 25% | 50% | 75% | 97.50% | Effective N | Rhat
Chen et al. (2010b) | b | 0.0807 | 0.0001 | 0.0274 | 0.0287 | 0.0613 | 0.0803 | 0.0995 | 0.1347 | 44054 | 1.0001
Chen et al. (2010b) | μ(δ) | 9.5659 | 0.0074 | 2.2186 | 5.798 | 7.9934 | 9.3626 | 10.9208 | 14.458 | 89562 | 1
Chen et al. (2010b) | OR_RR[1] | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 49930 | 0.9999
Chen et al. (2010b) | OR_RR[2] | 1.0259 | 0 | 0.008 | 1.0104 | 1.0203 | 1.0258 | 1.0314 | 1.0417 | 44131 | 1.0001
Chen et al. (2010b) | OR_RR[3] | 1.1132 | 0.0002 | 0.035 | 1.0465 | 1.089 | 1.1127 | 1.1367 | 1.1829 | 45864 | 1.0001
Chen et al. (2010b) | OR_RR[4] | 1.4298 | 0.0006 | 0.1395 | 1.172 | 1.3326 | 1.4241 | 1.5208 | 1.7185 | 50443 | 1.0001
Chen et al. (2010b) | OR_RR[5] | 5.2986 | 0.0093 | 2.1962 | 2.1114 | 3.7287 | 4.941 | 6.4635 | 10.5324 | 55717 | 1
Steinmaus et al. (2013) | b | 0.4548 | 0.0006 | 0.121 | 0.2263 | 0.3709 | 0.452 | 0.5362 | 0.6981 | 38132 | 1.0001
Steinmaus et al. (2013) | vlambda[1] | 1.1207 | 0.003 | 0.6553 | 0.2286 | 0.6447 | 0.9925 | 1.4639 | 2.7344 | 47264 | 1
Steinmaus et al. (2013) | vlambda[2] | 1.1944 | 0.0032 | 0.6977 | 0.2456 | 0.6886 | 1.0596 | 1.558 | 2.911 | 46721 | 1
Steinmaus et al. (2013) | vlambda[3] | 0.6756 | 0.0019 | 0.4024 | 0.1356 | 0.3839 | 0.5953 | 0.8811 | 1.6708 | 46083 | 1
Steinmaus et al. (2013) | OR_RR[1] | 1 | NaN | 0 | 1 | 1 | 1 | 1 | 1 | NaN | NaN
Steinmaus et al. (2013) | OR_RR[2] | 1.4556 | 0.0005 | 0.126 | 1.2274 | 1.3676 | 1.4495 | 1.5357 | 1.7206 | 52584 | 1
Steinmaus et al. (2013) | OR_RR[3] | 3.4633 | 0.0043 | 0.9809 | 1.9501 | 2.763 | 3.3304 | 4.0104 | 5.7716 | 51639 | 1
Wu et al. (2013) | b | 2.9557 | 0.0024 | 0.4833 | 2.0098 | 2.63 | 2.9516 | 3.2797 | 3.9141 | 40128 | 1
Wu et al. (2013) | vlambda[1] | 0.9715 | 0.0026 | 0.5645 | 0.1997 | 0.5567 | 0.8668 | 1.2661 | 2.3521 | 45906 | 1
Wu et al. (2013) | vlambda[2] | 1.0758 | 0.0029 | 0.6241 | 0.2221 | 0.6166 | 0.9587 | 1.4057 | 2.5956 | 45709 | 1
Wu et al. (2013) | vlambda[3] | 0.9571 | 0.0026 | 0.5577 | 0.197 | 0.5471 | 0.8519 | 1.248 | 2.3317 | 45831 | 1
Wu et al. (2013) | OR_RR[1] | 1 | NaN | 0 | 1 | 1 | 1 | 1 | 1 | NaN | NaN
Wu et al. (2013) | OR_RR[2] | 1.4232 | 0.0004 | 0.0855 | 1.2644 | 1.3643 | 1.42 | 1.4789 | 1.6 | 42172 | 1
Wu et al. (2013) | OR_RR[3] | 3.6475 | 0.0037 | 0.7652 | 2.3784 | 3.1037 | 3.5636 | 4.1036 | 5.3714 | 43299 | 1
Bates et al. (1995) | b | 0.4321 | 0.0054 | 1.4457 | –2.4462 | –0.436 | 0.4218 | 1.2829 | 3.3508 | 70756 | 1
Bates et al. (1995) | vlambda[1] | 1.1087 | 0.003 | 0.5716 | 0.296 | 0.6918 | 1.0084 | 1.4213 | 2.4747 | 37191 | 1
Bates et al. (1995) | vlambda[2] | 1.1018 | 0.003 | 0.5665 | 0.2942 | 0.6882 | 1.0046 | 1.408 | 2.4581 | 36711 | 1
Bates et al. (1995) | vlambda[3] | 0.7699 | 0.0021 | 0.4036 | 0.2002 | 0.4775 | 0.6989 | 0.9828 | 1.7536 | 37321 | 1
Bates et al. (1995) | vlambda[4] | 1.0204 | 0.0027 | 0.5261 | 0.2708 | 0.6372 | 0.9276 | 1.3065 | 2.2801 | 36948 | 1
Bates et al. (1995) | OR_RR[1] | 1 | NaN | 0 | 1 | 1 | 1 | 1 | 1 | NaN | NaN
Bates et al. (1995) | OR_RR[2] | 1.0023 | 0 | 0.0075 | 0.9875 | 0.9978 | 1.0021 | 1.0066 | 1.0176 | 70079 | 1
Bates et al. (1995) | OR_RR[3] | 1.0044 | 0.0001 | 0.0144 | 0.9761 | 0.9957 | 1.0041 | 1.0127 | 1.034 | 70051 | 1
Bates et al. (1995) | OR_RR[4] | 1.0127 | 0.0002 | 0.0402 | 0.9352 | 0.9882 | 1.0115 | 1.0356 | 1.0969 | 69823 | 1
Steinmaus et al. (2003) | b | –0.3131 | 0.0052 | 1.1289 | –2.709 | −1.0125 | –0.2631 | 0.4343 | 1.8097 | 46497 | 1.0002
Steinmaus et al. (2003) | vlambda[1] | 1.0018 | 0.0027 | 0.5838 | 0.2025 | 0.5755 | 0.8912 | 1.3072 | 2.4288 | 46331 | 1
Steinmaus et al. (2003) | vlambda[2] | 1.0001 | 0.0027 | 0.5827 | 0.2018 | 0.5759 | 0.8893 | 1.3031 | 2.4207 | 45223 | 1
Steinmaus et al. (2003) | vlambda[3] | 0.9992 | 0.0027 | 0.5841 | 0.2014 | 0.5732 | 0.8866 | 1.3046 | 2.4339 | 46700 | 1
Steinmaus et al. (2003) | OR_RR[1] | 1 | NaN | 0 | 1 | 1 | 1 | 1 | 1 | NaN | NaN
Steinmaus et al. (2003) | OR_RR[2] | 0.9985 | 0 | 0.0052 | 0.9874 | 0.9953 | 0.9988 | 1.002 | 1.0082 | 63180 | 1.0001
Steinmaus et al. (2003) | OR_RR[3] | 0.972 | 0.0005 | 0.1264 | 0.7277 | 0.8883 | 0.9698 | 1.0522 | 1.2302 | 59626 | 1.0001
Bates et al. (2004) | b | –0.1572 | 0.0004 | 0.079 | –0.3264 | –0.2071 | –0.152 | –0.1015 | –0.0187 | 44791 | 1.0001
Bates et al. (2004) | vlambda[1] | 2.773 | 0.007 | 1.4048 | 0.7584 | 1.7484 | 2.5299 | 3.5424 | 6.1488 | 40782 | 1
Bates et al. (2004) | vlambda[2] | 0.2716 | 0.0008 | 0.1606 | 0.0637 | 0.1569 | 0.2378 | 0.3485 | 0.6735 | 43151 | 1.0001
Bates et al. (2004) | vlambda[3] | 0.5045 | 0.0014 | 0.2805 | 0.127 | 0.3027 | 0.4491 | 0.6453 | 1.2061 | 41528 | 1
Bates et al. (2004) | vlambda[4] | 0.4398 | 0.0013 | 0.272 | 0.0969 | 0.2467 | 0.3798 | 0.5666 | 1.1274 | 43809 | 1.0001
Bates et al. (2004) | OR_RR[1] | 1 | NaN | 0 | 1 | 1 | 1 | 1 | 1 | NaN | NaN
Bates et al. (2004) | OR_RR[2] | 0.8789 | 0.0003 | 0.0554 | 0.7676 | 0.8422 | 0.8798 | 0.9166 | 0.9837 | 45505 | 1.0001
Bates et al. (2004) | OR_RR[3] | 0.7461 | 0.0005 | 0.1068 | 0.5456 | 0.6725 | 0.743 | 0.8162 | 0.9627 | 46209 | 1.0001
Bates et al. (2004) | OR_RR[4] | 0.2957 | 0.001 | 0.2089 | 0.0588 | 0.1532 | 0.2434 | 0.3776 | 0.8345 | 45364 | 1
Meliker et al. (2010) | b | 0.1587 | 0.0023 | 0.6344 | –1.1105 | –0.2625 | 0.1649 | 0.5851 | 1.3984 | 79258 | 1
Meliker et al. (2010) | vlambda[1] | 1.4715 | 0.004 | 0.85 | 0.31 | 0.8455 | 1.3066 | 1.9159 | 3.5509 | 45896 | 1
Meliker et al. (2010) | vlambda[2] | 1.2509 | 0.0033 | 0.7235 | 0.2635 | 0.7177 | 1.1103 | 1.6298 | 3.0253 | 46757 | 1
Meliker et al. (2010) | vlambda[3] | 0.2826 | 0.0008 | 0.1689 | 0.0578 | 0.1589 | 0.2486 | 0.3686 | 0.6971 | 45618 | 1
Meliker et al. (2010) | OR_RR[1] | 1 | NaN | 0 | 1 | 1 | 1 | 1 | 1 | NaN | NaN
Meliker et al. (2010) | OR_RR[2] | 1.0053 | 0.0001 | 0.0207 | 0.9648 | 0.9915 | 1.0053 | 1.019 | 1.0465 | 81000 | 1
Meliker et al. (2010) | OR_RR[3] | 1.0794 | 0.0008 | 0.2332 | 0.6876 | 0.9149 | 1.0572 | 1.218 | 1.6036 | 75713 | 1
Baris et al. (2016) | b | 0.994 | 0.0023 | 0.6715 | –0.2862 | 0.5377 | 0.9783 | 1.436 | 2.3396 | 82421 | 1
Baris et al. (2016) | vlambda[1] | 1.4285 | 0.004 | 0.5855 | 0.5191 | 1.0031 | 1.3477 | 1.7671 | 2.7936 | 21968 | 1
Baris et al. (2016) | vlambda[2] | 1.6025 | 0.0045 | 0.6562 | 0.5837 | 1.1232 | 1.5145 | 1.9855 | 3.1225 | 21038 | 1
Baris et al. (2016) | vlambda[3] | 1.5278 | 0.0043 | 0.625 | 0.5559 | 1.0712 | 1.4442 | 1.8908 | 2.988 | 21298 | 1
Baris et al. (2016) | vlambda[4] | 1.1268 | 0.0032 | 0.4623 | 0.4101 | 0.7895 | 1.0638 | 1.3973 | 2.2026 | 21478 | 1
Baris et al. (2016) | vlambda[5] | 0.1584 | 0.0005 | 0.0687 | 0.0551 | 0.1085 | 0.1484 | 0.1968 | 0.3202 | 22367 | 1
Baris et al. (2016) | vlambda[6] | 0.1423 | 0.0004 | 0.0639 | 0.048 | 0.0958 | 0.1322 | 0.1771 | 0.2932 | 23593 | 1
Baris et al. (2016) | OR_RR[1] | 1 | NaN | 0 | 1 | 1 | 1 | 1 | 1 | NaN | NaN
Baris et al. (2016) | OR_RR[2] | 1.0071 | 0 | 0.0049 | 0.998 | 1.0038 | 1.007 | 1.0103 | 1.017 | 84655 | 1
Baris et al. (2016) | OR_RR[3] | 1.0222 | 0.0001 | 0.0152 | 0.9938 | 1.0118 | 1.0217 | 1.0322 | 1.0532 | 84760 | 1
Baris et al. (2016) | OR_RR[4] | 1.0653 | 0.0002 | 0.0451 | 0.9824 | 1.0342 | 1.0632 | 1.0945 | 1.1587 | 84834 | 1
Baris et al. (2016) | OR_RR[5] | 1.1989 | 0.0005 | 0.1426 | 0.9512 | 1.0989 | 1.1872 | 1.287 | 1.5074 | 83650 | 1
Baris et al. (2016) | OR_RR[6] | 1.4142 | 0.0011 | 0.3152 | 0.9115 | 1.191 | 1.3736 | 1.5944 | 2.1342 | 79647 | 1
Chang et al. (2016) | b | 0.0956 | 0.0002 | 0.0458 | 0.0117 | 0.0637 | 0.0937 | 0.1257 | 0.1891 | 47248 | 1.0001
Chang et al. (2016) | vlambda[1] | 1.0456 | 0.0029 | 0.6189 | 0.2098 | 0.5959 | 0.9274 | 1.366 | 2.5524 | 44915 | 1
Chang et al. (2016) | vlambda[2] | 0.9753 | 0.0027 | 0.5761 | 0.194 | 0.557 | 0.8656 | 1.273 | 2.3878 | 46906 | 1
Chang et al. (2016) | vlambda[3] | 0.9857 | 0.0028 | 0.5872 | 0.1974 | 0.5595 | 0.8708 | 1.2836 | 2.4286 | 44337 | 1
Chang et al. (2016) | OR_RR[1] | 1 | NaN | 0 | 1 | 1 | 1 | 1 | 1 | NaN | NaN
Chang et al. (2016) | OR_RR[2] | 1.1394 | 0.0003 | 0.0667 | 1.0168 | 1.0929 | 1.1368 | 1.183 | 1.2759 | 47485 | 1
Chang et al. (2016) | OR_RR[3] | 1.6513 | 0.0017 | 0.3599 | 1.064 | 1.3937 | 1.6127 | 1.8657 | 2.4553 | 46908 | 1
Karagas et al. (2004) | b | 0.3369 | 0.0054 | 1.4401 | –2.5727 | –0.5132 | 0.3394 | 1.2039 | 3.2037 | 72176 | 0.9999
Karagas et al. (2004) | vlambda[1] | 1.6667 | 0.0045 | 0.6404 | 0.6577 | 1.2026 | 1.5872 | 2.0456 | 3.1281 | 20705 | 1
Karagas et al. (2004) | vlambda[2] | 2.0761 | 0.0055 | 0.7935 | 0.8238 | 1.4981 | 1.979 | 2.5429 | 3.8853 | 20715 | 1
Karagas et al. (2004) | vlambda[3] | 1.638 | 0.0043 | 0.6281 | 0.6463 | 1.1824 | 1.5603 | 2.0103 | 3.0775 | 20888 | 1
Karagas et al. (2004) | vlambda[4] | 0.8972 | 0.0024 | 0.349 | 0.3507 | 0.6437 | 0.8508 | 1.1022 | 1.7043 | 21211 | 1
Karagas et al. (2004) | vlambda[5] | 0.3638 | 0.001 | 0.1479 | 0.1377 | 0.2561 | 0.3438 | 0.4474 | 0.7091 | 22239 | 1
Karagas et al. (2004) | vlambda[6] | 0.1101 | 0.0003 | 0.0515 | 0.0367 | 0.0727 | 0.1014 | 0.1373 | 0.2349 | 24741 | 1
Karagas et al. (2004) | vlambda[7] | 0.2313 | 0.0006 | 0.0976 | 0.0844 | 0.1604 | 0.2168 | 0.2857 | 0.46 | 22684 | 1
Karagas et al. (2004) | OR_RR[1] | 1 | NaN | 0 | 1 | 1 | 1 | 1 | 1 | NaN | NaN
Karagas et al. (2004) | OR_RR[2] | 1.0011 | 0 | 0.0046 | 0.9919 | 0.9984 | 1.0011 | 1.0038 | 1.0102 | 73902 | 0.9999
Karagas et al. (2004) | OR_RR[3] | 1.0019 | 0 | 0.008 | 0.9859 | 0.9972 | 1.0019 | 1.0066 | 1.0179 | 73916 | 0.9999
Karagas et al. (2004) | OR_RR[4] | 1.0033 | 0.0001 | 0.0136 | 0.976 | 0.9952 | 1.0032 | 1.0113 | 1.0307 | 73931 | 0.9999
Karagas et al. (2004) | OR_RR[5] | 1.0069 | 0.0001 | 0.0279 | 0.9514 | 0.9901 | 1.0065 | 1.0232 | 1.0638 | 73916 | 0.9999
Karagas et al. (2004) | OR_RR[6] | 1.0085 | 0.0001 | 0.0342 | 0.9409 | 0.988 | 1.008 | 1.0284 | 1.0786 | 73886 | 0.9999
Karagas et al. (2004) | OR_RR[7] | 1.0127 | 0.0002 | 0.0497 | 0.9157 | 0.9826 | 1.0115 | 1.0414 | 1.1156 | 73731 | 0.9999
Michaud et al. (2004) | b | 0.5248 | 0.0053 | 1.3726 | –2.1534 | –0.3261 | 0.5023 | 1.3446 | 3.3746 | 66105 | 1
Michaud et al. (2004) | vlambda[1] | 1.294 | 0.0035 | 0.6533 | 0.3496 | 0.8162 | 1.1851 | 1.6532 | 2.8466 | 34266 | 1.0001
Michaud et al. (2004) | vlambda[2] | 0.9105 | 0.0025 | 0.4611 | 0.2455 | 0.5729 | 0.8342 | 1.1633 | 2.0002 | 34658 | 1.0001
Michaud et al. (2004) | vlambda[3] | 0.9325 | 0.0025 | 0.4724 | 0.2514 | 0.5881 | 0.8532 | 1.1909 | 2.0601 | 34537 | 1.0001
Michaud et al. (2004) | vlambda[4] | 0.8632 | 0.0024 | 0.4377 | 0.2325 | 0.543 | 0.7882 | 1.1035 | 1.909 | 34380 | 1.0001
Michaud et al. (2004) | OR_RR[1] | 1 | NaN | 0 | 1 | 1 | 1 | 1 | 1 | NaN | NaN
Michaud et al. (2004) | OR_RR[2] | 1.0059 | 0.0001 | 0.0152 | 0.9766 | 0.9965 | 1.0055 | 1.0148 | 1.0378 | 73713 | 1
Michaud et al. (2004) | OR_RR[3] | 1.0123 | 0.0001 | 0.0312 | 0.9528 | 0.9928 | 1.0112 | 1.0305 | 1.0787 | 73499 | 1
Michaud et al. (2004) | OR_RR[4] | 1.0302 | 0.0003 | 0.074 | 0.894 | 0.9834 | 1.0262 | 1.0722 | 1.1915 | 72608 | 1
Pooled β_mean | | 0.3694 | 0.003 | 0.3393 | 0.001 | 0.0874 | 0.2861 | 0.5651 | 1.2013 | 12891 | 1.0003
β_sigma | | 1.3449 | 0.0031 | 0.4828 | 0.6845 | 1.0115 | 1.2531 | 1.5729 | 2.5405 | 24247 | 1.0003
Power | | 1.089 | 0.0008 | 0.0863 | 1.0024 | 1.0273 | 1.0642 | 1.1236 | 1.317 | 10974 | 1.0006

a The indices, e.g., OR[i] refer to the ith group in the study. The lambda values that characterize the proportion of the control population in each dose-range are computed by vlambda[i]/sum(vlambda[j]) for all i, j in the range appropriate for each study.

For each parameter, n_eff is a crude measure of effective sample size, and Rhat is the potential scale reduction factor on split chains (at convergence, Rhat = 1).

Figure C-12 Posterior distributions for bladder cancer pooled (bmean) and data-set-specific (b) logistic slope parameters, using MLE dose estimates

95% Credible intervals are highlighted.

Figure C-13 Non-hierarchical dose response curves for individual bladder cancer studies; using MLE dose estimates

Figure C-14 Non-hierarchical dose response curve for Steinmaus et al. (2013) with high dose dropped; using MLE dose estimates

Figure C-15 Hierarchical dose response curves for individual bladder cancer studies (using MLE dose estimates)

##### Model fit/Convergence for bladder cancer dose-response meta-analysis

Overall, the Stan^®^ software used to perform the dose-response meta-analysis modeling indicates model fit/convergence was good for the bladder cancer outcomes. An indicator of model convergence the Stan software provides is the number of divergent transitions in the Hamiltonian Markov chain.^28^ The software reported divergences for less than 0.3% (n = 132) of the post-warmup iterations for the EPA Bladder cancer dose-response meta-analysis. Although the presence of divergent transitions in the posterior may be of concern, the total number of divergent transitions was small compared to the total number of post-warmup iterations and the location of the divergent transitions appear to be randomly distributed throughout the posterior (see Figure C-16). Thus, there does not appear to be one particular location in the posterior geometry particularly affected by the presence of divergent transitions. Additionally, the RHat value for all estimated parameters was good (i.e., values very close to 1), further indicating good model fit and performance.

Figure C-16 Pairs plots for bladder cancer analysis, divergent transitions marked in red

##### Bladder cancer sensitivity analyses

In addition to the evaluation of the dose-response meta-analysis approach’s sensitivity across endpoints to the choice of the simpler Logistic-power model over a more complex double Hill model that allows for non-monotonicity (see Sensitivity Analysis of Possible Non-monotonic Dose-Response Relationships), EPA has examined the sensitivity of the estimates of the association between oral iAs exposure and each dose-response meta-analysis endpoint for ten sources of uncertainty, as follows: (1) characterization of the exposure levels used for the dose-response modeling, (2) the choice of data sets, (3) the assumption that the general U.S. population is not appreciably exposed to iAs via inhalation, (4) consideration of a “high-end” estimate for the U.S. background iAs exposure level, (5) considerations of alternative gamma prior distributions for the pooled slope parameter, (6) the use of urine biomarker studies (if available) in the dose-response meta-analysis, (7) the use of alternative exposure metrics and/or lagged analyses within studies (if applicable), (8) the calculation of the cancer slope factor with varying numbers of doses, (9) the use of a prior for the pooled slope that allows negative values, and (10) use of the logistic-power model vs. the logistic model. Note, for sensitivity analyses (1–2) and (5–7) the pooled slope parameters were estimated using the logistic model with the power parameter set to 1.089 (i.e., not estimated via MCMC sampling) as to facilitate direct comparison of pooled logistic slopes. To minimize computational burden, different MCMC settings were used than the main analysis: 25,000 iterations, 75% warm-up ratio, thin = 1. Consequently, the MLE results presented in Table C-27 are very similar, but not exactly equal to the main analysis MLE results. As such, the results of sensitivity analyses (1–2) and (5–7) should be compared to the MLE results in Table C-27. Sensitivity analyses (3–4) and (8–10) involved modeling and then calculation of lifetime extra risks for comparison, therefore, the results of these sensitivity analyses can be compared to the main analysis.

The sources of uncertainty related to dose metric values are themselves broken down into two components. The first arises because of the need to estimate a mean value for the dose groups reported in terms of ranges of values (in whatever exposure metric). The second relates to conversion of those mean exposure values to a consistent set of units across studies, those units being average daily μg/kg–day. The methods used to characterize those uncertainties are described in Allen et al. (2020a). Table C-27 below summarizes the 95% confidence intervals for the dose-response meta-analysis pooled b values for bladder cancer for the “MLE,” “low,” and “high” iAs dose estimates shown in Table C-25.^29^ Note that, while the “low” dose estimates provide the largest pooled slope estimates, the mean pooled slope for the “low” dose estimate is only 8% higher than the mean slope for the MLE dose estimates, and the 95th upper bound for the “low” dose estimate is only 11% higher than the MLE estimate, indicating that the analysis was relatively insensitive to the uncertainties associated with dose characterization.

Table C-27 Pooled mean b from dose-response meta-analysis of bladder cancer studies using MLE, “low,” and “high” dose estimates

| Pooled slope - low dose estimates | Pooled slope - MLE (MLE) dose estimates | Pooled slope - high dose estimates
5% | 0.0041 | 0.0048 | 0.0039
Mean | 0.3950 | 0.3642 | 0.3267
95% | 1.1393 | 1.0236 | 0.8801

With respect to sensitivity of the estimates to the choice of dataset, note that the dose-response meta-analysis approach avoids the issue of study selection by pooling the results of all the datasets. Nevertheless, it is of interest to determine how influential each of those studies are on the estimate of the pooled risk. That sensitivity has been investigated by computing the pooled estimate of risk when each of the data sets is iteratively excluded from the analysis (i.e., a leave-one-out analysis). Table C-28 lists the pooled and study-specific mean b values when one study is iteratively left out of the analysis. As can be seen, the greatest decrease (68%) is observed when the dataset from Wu et al. (2013) is excluded, and the greatest increase (16%) is observed when the dataset from Bates et al. (2004) is excluded. Uncertainty in how seafood consumption and arsenobetaine concentrations in the urine may impact modeling results can be ascertained by considering the pooled slope when the Chang et al. (2016) study is excluded. This is the only urine study that failed to address arsenobetaine when estimating the urinary concentration of total urinary arsenic. Failure to consider arsenobetaine does not appear to greatly impact the results of modeling as excluding the Chang et al. (2016) study only increases the pooled logistic slope by approximately 9%.

Although inhalation of inorganic arsenic is not considered a primary route of exposure for the general public, the World Health Organization (WHO) estimates that background exposure may range from 0.02 to 0.6 μg/day in areas without substantial arsenic emissions from anthropogenic sources. Assuming an average body weight of 70 kg, this corresponds to daily intake values of 2.9 × 10⁻^4^ μg/kg-day to 8.6 × 10⁻^3^ μg/kg-day. The third sensitivity analysis involved two extra lifetable analyses wherein background inhalation components of either 4.4 × 10⁻^3^ μg/kg-day (corresponding to the midpoint of the range of reported background iAs concentrations), or 8.6 × 10⁻^3^ μg/kg-day (corresponding to the upper limit of background concentrations) were added to the original background estimate of exposure due to dietary and drinking water sources (i.e., 0.0365 μg/kg-day). Incorporation of inhalation exposures in the background estimate of total exposure also did not result in appreciably different estimates of extra risk. By definition, as the estimate of background exposure increased in the lifetable analysis, calculated extra risks must correspondingly decrease. Thus, at a 0.13 μg/kg-day dose (approximately equivalent to a 10 μg/L iAs lifetime drinking water exposure), when the assumed background exposure was either 0.0409 μg/kg–day or 0.0451 μg/kg–day, extra risks decreased to 7.85 × 10⁻^4^ or 7.83 × 10⁻^4^, compared to 7.87 × 10⁻^4^ when no inhalation component was included in the background estimate of exposure. This corresponds to 0.2% and 0.5% decreases in extra risk, respectively. Changes in lifetime extra risk were even smaller at the assumed background exposure level of 0.0365 μg/kg–day: 1.95 × 10⁻^4^ for both the low and high inhalation scenarios versus 1.96 × 10⁻^4^ for the main analysis.

Table C-28 Results of the leave-one-out analysis for bladder cancer datasets using the MLE dose estimate

Study left out | Mean b values (5th–95th percentile)
Study left out | Pooled^a^ | Chen et al. (2010b) | Steinmaus et al. (2013) | Wu et al. (2013) | Bates et al. (1995) | Steinmaus et al. (2003) | Bates et al. (2004) | Meliker et al. (2010) | Baris et al. (2016) | Chang et al. (2016) | Karagas et al. (2004) | Michaud et al. (2004)
Chen et al. (2010b) | 0.4054 (0.0040–1.1395) | -- | 0.4496 (0.2798–0.6222) | 3.0111 (2.2433–3.7824) | 0.4961 (−2.1442–3.1583) | −0.3828 (−2.4255–1.4733) | −0.1546 (−0.2784–0.0389) | 0.1643 (−0.8841–1.2083) | 1.0390 (−0.0572–2.1724) | 0.0943 (0.0232–0.1646) | 0.3554 (−2.2516–2.8964) | 0.5766 (−1.7915–3.0548)
Steinmaus et al. (2013) | 0.3679 (0.0040–1.0802) | 0.0782 (0.0441–0.1105) | -- | 3.0110 (2.2413–3.7821) | 0.4589 (−2.1378–3.1447) | −0.3965 (−2.4623–1.5016) | −0.1548 (−0.2789–0.0406) | 0.1463 (−0.9065–1.1949) | 1.0300 (−0.0699–2.1645) | 0.0939 (0.0240–0.1644) | 0.3189 (−2.2227–2.8476) | 0.5584 (−1.8143–3.0759)
Wu et al. (2013) | 0.1165 (0.0012–0.3364) | 0.0781 (0.0442–0.1105) | 0.3932 (0.2165–0.5711) | -- | 0.1198 (−0.4431–0.7239) | 0.0523 (−0.5316–0.6075) | −0.1338 (−0.2539–0.0196) | 0.1054 (−0.3847–0.6127) | 0.2834 (−0.1763–0.9292) | 0.0933 (0.0244–0.1627) | 0.1150 (−0.4588–0.7265) | 0.1324 (−0.4338–0.7662)
Bates et al. (1995) | 0.3611 (0.0038–1.0155) | 0.0783 (0.0447–0.1103) | 0.4491 (0.2793–0.6204) | 2.9543 (2.1698–3.7393) | -- | −0.3273 (−2.2700–1.4185) | −0.1552 (−0.2791–0.0415) | 0.1588 (−0.8874–1.1903) | 0.9928 (−0.0734–2.0999) | 0.0938 (0.0242–0.1647) | 0.3248 (−1.9865–2.6206) | 0.5184 (−1.6453–2.7746)
Steinmaus et al. (2003) | 0.4110 (0.0057–1.1090) | 0.0780 (0.0437–0.1107) | 0.4492 (0.2791–0.6187) | 2.9641 (2.1948–3.7555) | 0.4764 (−1.8826–2.9341) | -- | −0.1541 (−0.2767–0.0406) | 0.1723 (−0.8815–1.2226) | 1.0138 (−0.0755–2.1352) | 0.0938 (0.0238–0.1639) | 0.3658 (−1.9394–2.6834) | 0.5624 (−1.6770–2.8787)
Bates et al. (2004) | 0.4228 (0.0058–1.1730) | 0.0781 (0.0442–0.1106) | 0.4505 (0.2833–0.6195) | 3.0003 (2.2048–3.7943) | 0.4978 (−2.0777–3.1387) | −0.3539 (−2.4363–1.5102) | -- | 0.1619 (−0.8945–1.1897) | 1.0361 (−0.0488–2.1553) | 0.0942 (0.0240–0.1642) | 0.3704 (−2.1569–2.8698) | 0.5909 (−1.7831–3.0213)
Meliker et al. (2010) | 0.3882 (0.0044–1.1052) | 0.0781 (0.0437–0.1109) | 0.4488 (0.2804–0.6178) | 2.9982 (2.2128–3.7824) | 0.4604 (−2.0989–3.0484) | −0.3844 (−2.4334–1.4499) | −0.1543 (−0.2781–0.0402) | -- | 1.0316 (−0.0734–2.1721) | 0.0939 (0.0250–0.1638) | 0.3378 (−2.2148–2.8431) | 0.5727 (−1.7894–3.0226)
Baris et al. (2016) | 0.3410 (0.0030–1.0070) | 0.0782 (0.0440–0.1107) | 0.4483 (0.2799–0.6176) | 2.9785 (2.1890–3.7827) | 0.4055 (−2.0691–2.9482) | −0.3860 (−2.3687–1.4125) | −0.1555 (−0.2792–0.0426) | 0.1430 (−0.9177–1.1840) | -- | 0.0938 (0.0240–0.1642) | 0.3012 (−2.1459–2.7876) | 0.5151 (−1.7856–2.9165)
Chang et al. (2016) | 0.3951 (0.0042–1.1123) | 0.0782 (0.0443–0.1105) | 0.4496 (0.2828–0.6195) | 3.0133 (2.2350–3.7998) | 0.4899 (−2.1106–3.1224) | −0.4015 (−2.4815–1.4710) | −0.1550 (−0.2783–0.0394) | 0.1610 (−0.9032–1.2113) | 1.0382 (−0.0462–2.1824) | -- | 0.3344 (−2.2505–2.8720) | 0.5871 (−1.7639–3.0925)
Karagas et al. (2004) | 0.3682 (0.0046–1.0193) | 0.0783 (0.0444–0.1103) | 0.4502 (0.2817–0.6207) | 2.9512 (2.1729–3.7318) | 0.4355 (−1.8905–2.7707) | −0.3219 (−2.2471–1.4241) | −0.1547 (−0.2780–0.0399) | 0.1633 (−0.8906–1.2083) | 0.9970 (−0.0783–2.1191) | 0.0941 (0.0249–0.1628) | -- | 0.5134 (−1.6714–2.7956)
Michaud et al. (2004) | 0.3535 (0.0034–0.9856) | 0.0780 (0.0437–0.1105) | 0.4478 (0.2781–0.6191) | 2.9529 (2.1623–3.7366) | 0.4285 (−1.8624–2.7825) | −0.3368 (−2.2908–1.4452) | −0.1546 (−0.2775–0.0405) | 0.1460 (−0.9196–1.1768) | 0.9918 (−0.0729–2.1063) | 0.0940 (0.0251–0.1643) | 0.3115 (−2.0563–2.6541) | --

a Pooled estimate using all studies was 0.3642 (0.0048−1.0236) (see Table C-27).

Currently, the assessment uses an assumed background iAs exposure level of 0.0365 µg/kg-day based on a median background dietary exposure level of 0.02 µg iAs/kg-day (Xue et al., 2010) and 0.0165 µg iAs/kg-day from drinking water (estimated from the median U.S. Country average inorganic arsenic drinking water concentration [1.5 μg/L] from USGS data (Mendez et al., 2017) multiplied by the average water intake rate in the U.S. population of 0.011 L/kg-day [U.S. EPA (2019), Table 3-1, “All Ages”]). However, there is some uncertainty in the determination of this background exposure level and different values for the dietary and drinking water components of the estimate could have been used. For example, the mean dietary exposure level of 0.05 µg iAs/kg-day from Xue et al. (2010) could have been used, as well has a higher estimate of drinking water exposure of 0.06 µg iAs/kg-day, sourced from Mantha et al. (2016). Using this “high-end” estimate of 0.11 µg iAs/kg-day for the background iAs exposure only decreases the mean lifetime extra risk at the drinking water standard of 10 µg/L (corresponding to 0.13 µg/kg-day daily intake) 4.3%, thus indicating that the lifetable methods used are relatively insensitive to the estimates of U.S. background iAs exposure.

The assumption of different Gamma prior distributions for β_mean did not result in large differences in the posterior distributions of the β_mean parameter (see Table C-29). Interestingly, the alternative prior sensitivity results indicated that, for the present set of studies used in this case-example, the results of the dose-response meta-analysis are rather insensitive to assumptions on the gamma distribution prior. For example, using priors that differed with respect to the 1st percentile (i.e., 1.00001–20 and 1.001–20) resulted in the greatest differences in the mean of the posterior distribution relative to the original prior. This is due to the characteristics of the Gamma distribution, in which the greatest density with respect to probability of response is close to zero. So, when using the 1.00001–20 priors, the corresponding posterior mean distribution was approximately 8.9% lower than the results with the original prior because the 1st percentile is assumed to be ten times lower than for the original prior. Correspondingly, the 1.001–20 prior resulted in a posterior mean distribution approximately 16.4% higher than the original prior. Alternate Gamma prior distributions that differed with respect to the 99th percentile also did not differ greatly from the results using the original prior: using a prior with an upper bound of 10 (i.e., 50% lower than the original) resulted in a posterior mean approximately 8.6% lower, and using a prior with an upper bound of 30 (i.e., 50% higher than the original) resulted in a posterior mean approximately 2.1% higher than the original prior. This broadly indicates that the results of the analysis are heavily influenced by the actual data being modeled and are not inappropriately driven by the prior assumptions of the Bayesian modeling.

Table C-29 Posterior β_mean distribution values resulting from various prior Gamma distributions

Alternative Gamma prior | 5th percentile | Mean | 95th percentile | % Mean difference
1.00001–20; (a = 0.41, b = 1.01) | 0.0012 | 0.3316 | 0.9781 | –8.9%
1.0001–10; (a = 0.54, b = 1.49) | 0.0044 | 0.3326 | 0.9474 | −8.6%
1.0001–30; (a = 0.51, b = 0.99) | 0.0042 | 0.3718 | 1.0401 | 2.1%
1.001–20; (a = 0.71, b = 1.3) | 0.0167 | 0.4239 | 1.0678 | 16.4%
Original Prior (1.0001–20); (a = 0.52, b = 1.12) | 0.0048 | 0.3642 | 1.0236 | –

The outcome of the dose-response meta-analysis was sensitive to whether or not urinary biomarker studies were included in the modeling set. For bladder cancer, there were two urinary biomarker studies included the in the modeling set, Wu, and Chang. As can be seen in Table C-28, when Wu is left out of the modeling set, the mean logistic slope decreases approximately 68%, but when Chang is left out, the mean logistic slope increased 9%. When both studies are excluded, the mean logistic slope decreased to 0.1493, a 59% decrease compared to the mean logistic slope estimate of 0.3642 when all studies are included in the dose-response meta-analysis. A sensitivity analysis of only urine studies was not conducted as there are only two urine studies in the bladder cancer dose-response database. These results indicate that the urinary biomarker studies are important drivers of the overall estimated association between iAs exposure and bladder cancer in this dose-response meta-analysis.

The next sensitivity analysis for bladder cancer investigated the impact that alternative exposure metrics or lagged vs. unlagged analyses used in some studies had on the final dose-response meta-analysis results. Baris 2016 presented multiple results in their study using either µg/L drinking water, total mg consumed, or µg/day consumed as the exposure metric and analyses lagged 40 years or unlagged. The µg/L drinking water metric is excluded from this comparison because it is not considered to be as relevant as the consumption metrics. As noted previously, unless a population is limited in its source of fluids (e.g., populations that rely almost exclusively on a single well-water source), it is extremely important to survey individuals as to their consumption habits to approximate their actual iAs dose from the water source of interest. Baris et al. (2016) made a particular point of this, noting that “The contrast in our findings for cumulative arsenic intake and average arsenic concentration underscores the importance of incorporating water intake when estimating an individual’s total arsenic exposure in low to moderately exposed populations such as that in northern New England.” Baris et al. (2016) acknowledge that recall bias can be a concern with respect to the survey performed to obtain their consumption metric. However, to address recall bias, Baris et al. (2016) asked study participants if they “made a major change in their total water intake during their adult life.” When people that had made such a change were excluded from the analysis, the odds ratios by water intake were not substantially different than those for all participants. Further, Baris et al. (2016) asked subjects if they were aware of health risks due to arsenic in drinking water. The trend in risk was stronger in participants that reported no knowledge of arsenic risk (1.00, 0.89, 1.37, 1.39, and 2.18 for water intakes of ≤1.1, >1.1–1.5, >1.5–2.2, >2.2–3.8, and >3.8 L/day) compared to participants that reported they were aware of arsenic risks (1.00, 1.29, 1.02, 1.13, and 1.56 for water intakes of ≤1.1, >1.1–1.5, >1.5–2.2, >2.2–3.8, and >3.8 L/day). Baris et al. (2016) thus conclude it would be unlikely that unaware subjects had higher risks if recall bias were impacting the study’s results.

Table C-30 below shows the impact the most relevant alternative datasets in the dose-response meta-analysis on the final modeling results; the greatest difference was a 26% decrease in the estimated logistic slope when the 40-year lagged mg exposure metric was used from the Baris study.

Table C-30 Posterior β_mean distribution values resulting from the inclusion of alternative datasets in the dose-response meta-analysis

Alternative analysis | 5th percentile | Mean | 95th percentile | % Mean difference
Baris (lagged, mg) | 0.0019 | 0.2681 | 0.8605 | −26%
Baris (lagged, µg/d) | 0.0031 | 0.3001 | 0.8813 | −18%
Baris (unlagged, µg/d) | 0.0028 | 0.3066 | 0.8995 | −16%
Original Analysis (Baris, unlagged mg) | 0.0048 | 0.3642 | 1.0236 | –

Next was the consideration of whether the estimation of the cancer slope factor was influenced by the number of risk-at-a-dose values used to characterize the linear trendline. When estimating the cancer slope factor as the linear slope from 0 to 0.2 µg/kg-day using 21 risk-at-a-dose values (i.e., intervals of 0.01 µg/kg-day), a value of 1.76 × 10⁻^2^ per µg/kg-day was obtained (see Section 4.3.5 of main assessment). Varying the number of risk-at-a-dose values used to define the cancer slope factor from 11 to 41 resulted in cancer slope factors of 1.77 × 10⁻^2^ per µg/kg-day and 1.76 × 10⁻^2^ per µg/kg-day, respectively. Thus, the number of risk-at-a-dose values used to define the cancer slope factor appeared to have almost no effect on the estimated slope factor.

In the main analysis, the logistic-power model uses a gamma distribution for the prior over the pooled logistic slope parameter (i.e., bmean), reflecting the weight of evidence determination that iAs exposure is causal for the development of bladder cancer. The gamma distribution prior has the greatest density of prior weight on bmean values close to zero and inspection of the posterior distribution for this parameter reveals that the distribution still places high weight on small values (reflecting that many study-specific slope distributions place high weight on negative values). To investigate the degree to which the positivity constraint the gamma distribution places on the estimation of the bmean parameter, an alternative analysis was conducted using a normal (N(0,1)) distribution for the bmean parameter. Modeling of the bladder cancer data with this normal bmean parameter resulted in posterior distribution of 0.4600 (95%CI: −0.5124, 1.3524). and calculated mean and upper bound lifetime extra risks of 9 out of 10,000 and 26.5 out of 10,000 at 0.13 µg/kg-day (compared to 7.9 out of 10,000 and 22.4 out of 10,000 for the main analysis). Thus, while the use of a normal prior distribution for the bmean parameter does result in the posterior distribution spanning zero and returning negative values, the mean and upper bound lifetime extra risks resulting from modeling with this prior results in marginally (~13%–18%) increased risks compared to the main analysis.

Lastly, a sensitivity analysis was conducted to compare lifetime extra risks derived from modeling that used the logistic model instead of the logistic power model. In the main analysis, both models were not used as the logistic model is a degenerate form of the logistic-power model when power = 1. However, use the logistic-power model only resulted in an estimated power parameter = 1.089, which is very close to a value of 1. Mean and upper bound lifetime extra risks at 0.13 µg/kg-day, using the logistic model, were 9.4 out of 10,000 and 26.2 out of 10,000 (compared to 7.9 out of 10,000 and 22.4 out of 10,000 for the main analysis). This is to be expected as the use of the logistic-power model with power parameter values >1 implies greater curvature in the low dose region compared to the logistic model, resulting in lower lifetime extra risks.

##### Bladder cancer lifetime extra risk table

Table C-31 Bladder cancer lifetime extra risks for doses 0.005 µg/kg-day to 1.5 µg/kg-day

Dose | Mean | UCL
0.005 | 0.000023 | 0.000070
0.01 | 0.000049 | 0.000144
0.015 | 0.000075 | 0.000220
0.02 | 0.000102 | 0.000299
0.025 | 0.000130 | 0.000378
0.03 | 0.000158 | 0.000459
0.035 | 0.000187 | 0.000541
0.04 | 0.000216 | 0.000623
0.045 | 0.000245 | 0.000706
0.05 | 0.000275 | 0.000789
0.055 | 0.000305 | 0.000875
0.06 | 0.000336 | 0.000961
0.065 | 0.000366 | 0.001048
0.07 | 0.000397 | 0.001135
0.075 | 0.000428 | 0.001223
0.08 | 0.000460 | 0.001312
0.085 | 0.000491 | 0.001402
0.09 | 0.000523 | 0.001492
0.095 | 0.000555 | 0.001583
0.1 | 0.000588 | 0.001676
0.105 | 0.000620 | 0.001769
0.11 | 0.000653 | 0.001863
0.115 | 0.000686 | 0.001958
0.12 | 0.000719 | 0.002051
0.125 | 0.000753 | 0.002146
0.13 | 0.000787 | 0.002244
0.135 | 0.000820 | 0.002342
0.14 | 0.000855 | 0.002438
0.145 | 0.000889 | 0.002536
0.15 | 0.000923 | 0.002634
0.155 | 0.000958 | 0.002734
0.16 | 0.000993 | 0.002834
0.165 | 0.001028 | 0.002936
0.17 | 0.001064 | 0.003036
0.175 | 0.001099 | 0.003137
0.18 | 0.001135 | 0.003240
0.185 | 0.001171 | 0.003347
0.19 | 0.001207 | 0.003449
0.195 | 0.001243 | 0.003557
0.2 | 0.001280 | 0.003666
0.205 | 0.001316 | 0.003772
0.21 | 0.001353 | 0.003878
0.215 | 0.001390 | 0.003986
0.22 | 0.001428 | 0.004094
0.225 | 0.001465 | 0.004203
0.23 | 0.001503 | 0.004312
0.235 | 0.001541 | 0.004423
0.24 | 0.001579 | 0.004534
0.245 | 0.001617 | 0.004645
0.25 | 0.001655 | 0.004757
0.255 | 0.001694 | 0.004872
0.26 | 0.001733 | 0.004987
0.265 | 0.001772 | 0.005104
0.27 | 0.001811 | 0.005219
0.275 | 0.001850 | 0.005336
0.28 | 0.001890 | 0.005453
0.285 | 0.001930 | 0.005573
0.29 | 0.001970 | 0.005693
0.295 | 0.002010 | 0.005813
0.3 | 0.002050 | 0.005936
0.305 | 0.002091 | 0.006059
0.31 | 0.002132 | 0.006181
0.315 | 0.002173 | 0.006304
0.32 | 0.002214 | 0.006431
0.325 | 0.002255 | 0.006555
0.33 | 0.002297 | 0.006678
0.335 | 0.002339 | 0.006801
0.34 | 0.002380 | 0.006928
0.345 | 0.002423 | 0.007057
0.35 | 0.002465 | 0.007186
0.355 | 0.002508 | 0.007319
0.36 | 0.002550 | 0.007449
0.365 | 0.002593 | 0.007580
0.37 | 0.002636 | 0.007710
0.375 | 0.002680 | 0.007842
0.38 | 0.002723 | 0.007977
0.385 | 0.002767 | 0.008108
0.39 | 0.002811 | 0.008244
0.395 | 0.002855 | 0.008374
0.4 | 0.002900 | 0.008509
0.405 | 0.002944 | 0.008645
0.41 | 0.002989 | 0.008783
0.415 | 0.003034 | 0.008920
0.42 | 0.003079 | 0.009059
0.425 | 0.003125 | 0.009195
0.43 | 0.003170 | 0.009335
0.435 | 0.003216 | 0.009474
0.44 | 0.003262 | 0.009616
0.445 | 0.003308 | 0.009760
0.45 | 0.003355 | 0.009906
0.455 | 0.003402 | 0.010048
0.46 | 0.003448 | 0.010194
0.465 | 0.003496 | 0.010340
0.47 | 0.003543 | 0.010485
0.475 | 0.003590 | 0.010632
0.48 | 0.003638 | 0.010781
0.485 | 0.003686 | 0.010945
0.49 | 0.003734 | 0.011108
0.495 | 0.003783 | 0.011267
0.5 | 0.003832 | 0.011435
0.505 | 0.003880 | 0.011608
0.51 | 0.003930 | 0.011762
0.515 | 0.003979 | 0.011919
0.52 | 0.004028 | 0.012080
0.525 | 0.004078 | 0.012234
0.53 | 0.004128 | 0.012392
0.535 | 0.004178 | 0.012557
0.54 | 0.004229 | 0.012717
0.545 | 0.004280 | 0.012879
0.55 | 0.004331 | 0.013047
0.555 | 0.004382 | 0.013216
0.56 | 0.004433 | 0.013385
0.565 | 0.004485 | 0.013551
0.57 | 0.004537 | 0.013723
0.575 | 0.004589 | 0.013892
0.58 | 0.004641 | 0.014059
0.585 | 0.004694 | 0.014237
0.59 | 0.004747 | 0.014406
0.595 | 0.004800 | 0.014581
0.6 | 0.004853 | 0.014757
0.605 | 0.004906 | 0.014934
0.61 | 0.004960 | 0.015105
0.615 | 0.005014 | 0.015284
0.62 | 0.005069 | 0.015456
0.625 | 0.005123 | 0.015632
0.63 | 0.005178 | 0.015815
0.635 | 0.005233 | 0.015997
0.64 | 0.005288 | 0.016177
0.645 | 0.005344 | 0.016361
0.65 | 0.005400 | 0.016544
0.655 | 0.005456 | 0.016737
0.66 | 0.005512 | 0.016925
0.665 | 0.005569 | 0.017114
0.67 | 0.005626 | 0.017301
0.675 | 0.005683 | 0.017486
0.68 | 0.005740 | 0.017671
0.685 | 0.005798 | 0.017862
0.69 | 0.005856 | 0.018059
0.695 | 0.005914 | 0.018246
0.7 | 0.005972 | 0.018438
0.705 | 0.006031 | 0.018630
0.71 | 0.006090 | 0.018832
0.715 | 0.006149 | 0.019034
0.72 | 0.006209 | 0.019233
0.725 | 0.006269 | 0.019430
0.73 | 0.006329 | 0.019628
0.735 | 0.006389 | 0.019823
0.74 | 0.006450 | 0.020019
0.745 | 0.006511 | 0.020217
0.75 | 0.006572 | 0.020422
0.755 | 0.006633 | 0.020625
0.76 | 0.006695 | 0.020833
0.765 | 0.006757 | 0.021042
0.77 | 0.006819 | 0.021248
0.775 | 0.006882 | 0.021462
0.78 | 0.006945 | 0.021667
0.785 | 0.007008 | 0.021880
0.79 | 0.007072 | 0.022100
0.795 | 0.007135 | 0.022319
0.8 | 0.007200 | 0.022541
0.805 | 0.007264 | 0.022766
0.81 | 0.007329 | 0.022998
0.815 | 0.007394 | 0.023238
0.82 | 0.007459 | 0.023463
0.825 | 0.007525 | 0.023685
0.83 | 0.007591 | 0.023910
0.835 | 0.007657 | 0.024134
0.84 | 0.007723 | 0.024372
0.845 | 0.007790 | 0.024609
0.85 | 0.007857 | 0.024833
0.855 | 0.007925 | 0.025066
0.86 | 0.007993 | 0.025299
0.865 | 0.008061 | 0.025534
0.87 | 0.008129 | 0.025770
0.875 | 0.008198 | 0.026008
0.88 | 0.008267 | 0.026262
0.885 | 0.008337 | 0.026493
0.89 | 0.008406 | 0.026730
0.895 | 0.008477 | 0.026973
0.9 | 0.008547 | 0.027216
0.905 | 0.008618 | 0.027453
0.91 | 0.008689 | 0.027691
0.915 | 0.008760 | 0.027957
0.92 | 0.008832 | 0.028204
0.925 | 0.008904 | 0.028454
0.93 | 0.008976 | 0.028713
0.935 | 0.009049 | 0.028973
0.94 | 0.009122 | 0.029230
0.945 | 0.009196 | 0.029480
0.95 | 0.009270 | 0.029743
0.955 | 0.009344 | 0.029998
0.96 | 0.009418 | 0.030256
0.965 | 0.009493 | 0.030510
0.97 | 0.009569 | 0.030771
0.975 | 0.009644 | 0.031034
0.98 | 0.009720 | 0.031306
0.985 | 0.009797 | 0.031589
0.99 | 0.009873 | 0.031860
0.995 | 0.009950 | 0.032153
1 | 0.010028 | 0.032420
1.005 | 0.010106 | 0.032699
1.01 | 0.010184 | 0.032986
1.015 | 0.010262 | 0.033279
1.02 | 0.010341 | 0.033572
1.025 | 0.010421 | 0.033848
1.03 | 0.010500 | 0.034148
1.035 | 0.010580 | 0.034438
1.04 | 0.010661 | 0.034721
1.045 | 0.010742 | 0.035005
1.05 | 0.010823 | 0.035294
1.055 | 0.010905 | 0.035588
1.06 | 0.010987 | 0.035887
1.065 | 0.011069 | 0.036176
1.07 | 0.011152 | 0.036483
1.075 | 0.011235 | 0.036783
1.08 | 0.011319 | 0.037074
1.085 | 0.011403 | 0.037362
1.09 | 0.011487 | 0.037663
1.095 | 0.011572 | 0.037989
1.1 | 0.011657 | 0.038283
1.105 | 0.011743 | 0.038596
1.11 | 0.011829 | 0.038914
1.115 | 0.011916 | 0.039226
1.12 | 0.012003 | 0.039551
1.125 | 0.012090 | 0.039872
1.13 | 0.012178 | 0.040181
1.135 | 0.012266 | 0.040504
1.14 | 0.012355 | 0.040830
1.145 | 0.012444 | 0.041152
1.15 | 0.012533 | 0.041518
1.155 | 0.012623 | 0.041858
1.16 | 0.012714 | 0.042186
1.165 | 0.012805 | 0.042497
1.17 | 0.012896 | 0.042820
1.175 | 0.012988 | 0.043170
1.18 | 0.013080 | 0.043497
1.185 | 0.013172 | 0.043823
1.19 | 0.013266 | 0.044158
1.195 | 0.013359 | 0.044509
1.2 | 0.013453 | 0.044846
1.205 | 0.013548 | 0.045191
1.21 | 0.013643 | 0.045537
1.215 | 0.013738 | 0.045898
1.22 | 0.013834 | 0.046241
1.225 | 0.013930 | 0.046585
1.23 | 0.014027 | 0.046922
1.235 | 0.014124 | 0.047287
1.24 | 0.014222 | 0.047656
1.245 | 0.014320 | 0.048018
1.25 | 0.014419 | 0.048404
1.255 | 0.014518 | 0.048758
1.26 | 0.014618 | 0.049127
1.265 | 0.014718 | 0.049513
1.27 | 0.014819 | 0.049887
1.275 | 0.014920 | 0.050272
1.28 | 0.015022 | 0.050643
1.285 | 0.015124 | 0.051016
1.29 | 0.015227 | 0.051404
1.295 | 0.015330 | 0.051772
1.3 | 0.015434 | 0.052158
1.305 | 0.015538 | 0.052570
1.31 | 0.015643 | 0.052975
1.315 | 0.015748 | 0.053348
1.32 | 0.015854 | 0.053737
1.325 | 0.015960 | 0.054136
1.33 | 0.016067 | 0.054532
1.335 | 0.016174 | 0.054943
1.34 | 0.016282 | 0.055321
1.345 | 0.016390 | 0.055706
1.35 | 0.016499 | 0.056152
1.355 | 0.016609 | 0.056586
1.36 | 0.016719 | 0.057016
1.365 | 0.016829 | 0.057460
1.37 | 0.016940 | 0.057871
1.375 | 0.017052 | 0.058318
1.38 | 0.017164 | 0.058730
1.385 | 0.017277 | 0.059164
1.39 | 0.017390 | 0.059602
1.395 | 0.017504 | 0.060027
1.4 | 0.017619 | 0.060445
1.405 | 0.017734 | 0.060888
1.41 | 0.017849 | 0.061307
1.415 | 0.017965 | 0.061742
1.42 | 0.018082 | 0.062165
1.425 | 0.018199 | 0.062592
1.43 | 0.018317 | 0.063056
1.435 | 0.018435 | 0.063488
1.44 | 0.018554 | 0.063967
1.445 | 0.018674 | 0.064387
1.45 | 0.018794 | 0.064857
1.455 | 0.018915 | 0.065305
1.46 | 0.019036 | 0.065809
1.465 | 0.019158 | 0.066295
1.47 | 0.019281 | 0.066745
1.475 | 0.019404 | 0.067222
1.48 | 0.019527 | 0.067668
1.485 | 0.019652 | 0.068141
1.49 | 0.019777 | 0.068626
1.495 | 0.019902 | 0.069116
1.5 | 0.020028 | 0.069610

Extra risk at dose = 0 is zero by definition.

#### Oral Lung Cancer

##### Extrapolation of lung cancer extra risk to target U.S. population

Table C-32 Lifetable rates for all-cause mortality and lung cancer mortality and incidence

Age range | All-cause mortality rates (per 100,000)^a^ | Lung cancer mortality rates (per 100,000)^b^ | Lung cancer incidence rates (per 100,000)^b^
0–1 | 567 | 0 | 0
1–4 | 24.3 | 0 | 0.1
5–9 | 11.6 | 0 | 0
10–14 | 15.5 | 0 | 0
15–19 | 51.5 | 0 | 0.1
20–24 | 95.6 | 0 | 0.3
25–29 | 121 | 0.1 | 0.6
30–34 | 145.4 | 0.4 | 1.3
35–39 | 173.8 | 1.1 | 2.6
40–44 | 218.4 | 3.1 | 6.5
45–49 | 313.2 | 8.5 | 16.5
50–54 | 488 | 24.4 | 44.4
55–59 | 736.5 | 54.6 | 96.1
60–64 | 1,050.2 | 87.7 | 149.1
65–69 | 1,473.5 | 132.1 | 223.9
70–74 | 2,206.9 | 198.2 | 319.3
75–79 | 3,517.8 | 266 | 391.2
80–84 | 5,871.7 | 309.7 | 395.2

a All cause mortality: 2017 numbers, https://www.cdc.gov/nchs/data/nvsr/nvsr68/nvsr68_09-508.pdf.

b Cancer numbers: 2017 numbers, https://gis.cdc.gov/Cancer/USCS/DataViz.html.

##### Lung cancer study and dataset selection

Table C-33 describes the studies selected for the lung cancer Bayesian dose-response meta-analysis.

Table C-33 Data sets selected for oral exposure lung cancer Bayesian dose-response meta-analysis

Study/Meta-regression Dataset | Study design | Location | Exposure/dose metric | Estimate of iAs exposure group mean µg/kg-d daily intake range (Estimate of mean U.S. equivalent µg/L drinking water range)^a^ | Health outcome/endpoint | Description | Limitations
Argos et al. (2014); Table 1, Creatinine-adjusted urinary arsenic (µg/g) | Cohort | Bangladesh | Creatinine-adjusted urinary arsenic (µg/g) | 1.86–18.9; (167–1,716) | Lung cancer identified by trained physician via verbal autopsy questionnaire followed by review by panel of physicians. | Large cohort study (90 lung cancer deaths, total cohort size = 26,043) of Bangladeshi adults exposed to high levels of arsenic via drinking water; urinary total arsenic concentrations were measured from baseline spot urine samples; the analysis controlled for major confounders including smoking | Exposure estimates were based on a one-time baseline urine measurement; high level of detection for urinary arsenic compared to other urinary studies; relatively short follow-up time compared to other cohort studies included in meta-analysis
García-Esquinas et al. (2013); Table 3, Trachea, bronchus, and lung (ICD-9 162), Model 2 | Cohort | United States (Arizona, Oklahoma, North and South Dakota) | Creatinine-adjusted total urinary arsenic (µg/g) | 0.139–0.584; (10.8–51.3) | Trachea, bronchus, and lung tumors as identified by trained nosologist from death certificates and medical examiner reports (if available) | Large cohort study (78 lung cancer cases, total cohort size = 4,549) of Native Americans in multiple states exposed to relatively low levels of arsenic via drinking water and food; urinary total arsenic concentrations were measured from baseline spot urine samples; the analysis controlled for major confounders including smoking | Exposure estimates were based on a one-time baseline urine measurement; cohort size relatively small compared to other cohorts included in meta-analysis
Chen et al. (2010a); Table 2, Cumulative arsenic exposure | Cohort | NE Taiwan | Cumulative As exposure (µg/L*yr) | 0.77–18.97; (68.2–1,722) | Histologically confirmed lung cancers identified from Taiwan national cancer registry | Large cohort study (6,888 subjects with exposure measurements), individual well As levels measured for 85% of subjects. Broad exposure range, well-documented case ascertainment, good follow up (12 yr), controlled for major covariates. | No notable limitations
Dauphiné et al. (2013); Table 3, Cumulative exposure: 10-yr lag, Adjusted | Case-Control | United States (California, Nevada) | Cumulative As exposure (µg/L*yr) | 0.11–1.99; (8.2–179) | Histological confirmation of lung cancer from hospital records or state level cancer registries | Moderately (196 cases, 359 controls) large study of U.S. population exposed to mostly low levels of arsenic in water. Historical residential history, drinking water consumption questionnaire, and municipal drinking water/well As measurements used to estimate cumulative As exposure; major confounders adjusted for in final analyses | Possible recall bias (~47% of study questionnaires filled out by relatives/next-of-kin
Ferreccio et al. (2000); Table 5, OR Age- and Sex-Adjusted, High dose dropped | Case-Control | N. Chile | Average water As concentrati on (µg/L) | 1.1–3.1; (98.2–280) | Histologically confirmed lung cancer cases from public hospital records | Moderately (151 cases, 419 controls) large study of Chilean population exposed to As in municipal drinking water supplies; well-documented historical water As concentrations with good resolution in the low-medium dose range; The subject cohort has been the subject of a number of studies of As-related cancer and covariate interactions | Use of hospital controls; period of high exposure occurred many yr prior to study period (1958−1970), use of average As water concentrations during 1930−1994 could lead to exposure misclassification
Steinmaus et al. (2013); Table 3, Lifetime daily avg: all years | Case-Control | N. Chile | Lifetime daily average arsenic intake: all years (µg/d) | 1.3–10.8; (180–980) | Lung cancer cancers from all pathologists, hospitals, and radiologists in study area | Large case-control study (306 cases, 640 controls), well-documented historical water As exposures, good resolution in low-moderate exposure range. Residential and water use histories are used to estimate As intakes. The subject cohort has been the subject of a number of studies of As-related cancer and covariate interactions | Relied on municipal water As measurements for exposure estimates, but unique characteristics of study area (lack of alternative sources), suggest this is not a major source of uncertainty

a Estimated from µg/kg-d ranges (see Table C-36 assuming median U.S. dietary background of 0.02 µg/kg-d (Xue et al., 2010) and mean U.S. water consumption rate of 0.011 L/kg-d (see (U.S. EPA, 2011), Table 3-1, “All Ages”).

##### Comparison of studies selected for EPA dose-response meta-analysis and studies used in earlier meta-analyses

EPA found considerable overlap between the studies included in the EPA dose-response meta-analysis and those identified in earlier meta-analysis (see Table C-34). Of the six studies chosen by EPA, a core group of three studies were chosen for all (Steinmaus et al., 2013; Dauphiné et al., 2013; Chen et al., 2010a) of the meta-analyses published after them. Studies selected for the earlier meta-analyses that were not used by EPA tended to be superseded by later analyses of the same cohorts.

Table C-34 Comparison of study selection for EPA lung cancer dose-response meta-analysis compared to earlier meta-analyses

Study | EPA dose-response meta-analysis | Begum et al. (2012) | Lynch et al. (2017b) | Shao et al. (2021)
Argos et al. (2014) | ✔
Chen et al. (2004) | | ✔
Chen et al. (2010a) | ✔ | ✔ | ✔ | ✔
Chiou et al. (1995) | | ✔ | ✔
Dauphiné et al. (2013) | ✔ | | ✔ | ✔
D’Ippoliti et al. (2015) | | | ✔
Ferreccio et al. (2000) | ✔
García-Esquinas et al. (2013) | ✔
Heck et al. (2009) | | ✔
Mostafa et al. (2008) | | | ✔ | ✔
Smith et al. (2009) | | ✔ | ✔ | ✔
Steinmaus et al. (2013) | ✔ | | ✔ | ✔

Chiou et al. (1995): EPA chose not to use data from this study because it was based in the southwest Taiwan “endemic” area. Exposure level estimates were extremely uncertain and generally quite high, and the incidence of Blackfoot Disease and potential poor nutrition in the study subjects led EPA not to include the data.

Smith et al. (2009): This study was not included in EPA’s meta-analysis as the oral data included in Smith et al. (2009) is simply the data earlier reported in Ferreccio et al. (2000). Ferreccio et al. (2000) is included in EPA’s meta-analysis.

Heck et al. (2009): EPA’s rationale for not selecting this study was that the reported exposure range for the study dose-metric (toenail arsenic concentrations), once converted into daily intake, was prohibitively narrow, with only a 20% increase in the daily intake value over the entire exposure range.

Chen et al. (2004): EPA’s rationale for not selecting this study was two-fold: 1) this study included townships previously investigated in Chiou et al. (1995) and the concerns regarding exposure levels and incidence of Blackfoot Disease pertain to this study as well; and 2) the 4 N.E. Taiwan townships included in Chen et al. (2004) are also included in the analysis by Chen et al. (2010a), which has more years of follow-up than Chen et al. (2004) and presents As exposure as cumulative exposure, and therefore was judged by EPA to be the superior study for inclusion in the meta-analysis.

Finally, two studies were selected by EPA that were not included in any of the previous meta-analysis: Argos et al. (2014) and García-Esquinas et al. (2013). These studies were published after the Begum et al. (2012) meta-analysis and were urine biomarker studies from which EPA was able to estimate daily average intake using the empirical relationship between urinary and drinking water concentrations, as defined by the El-Masri-Kenyon PBPK model (El-Masri et al., 2018a, b). All previously published meta-analyses focused on drinking water studies.

While there are differences in the modeling approaches used by EPA and earlier meta-analyses, differing results can be attributed largely to study and data selection. As for bladder cancer, while the Lynch et al. (2017b) approach differed from EPA’s approach with respect to the exposure metric modeled and the lifetime adjustment method used, when the Lynch et al. (2017b) dataset was evaluated by both approaches, the lung cancer extra risk predictions were nearly identical (data not shown).

##### Lung cancer study-specific dose conversions

The study-specific dose conversions and confidence interval estimations were derived in Excel workbooks with the Yasai add-in to do Monte Carlo simulations. Each study required a potentially different set of assumptions for the dose conversions. The study-specific conversion assumptions and results are provided in the Excel files, which are included in the health outcome-specific intake uncertainty folders of Supplemental Material available from the arsenic dose-response supplemental files (U.S. EPA, 2025), which are accompanied by an explanatory structured workflow, outline and variable dictionary (U.S. EPA, 2024b). The following tables summarize the input equations and assumptions used in the Monte Carlo analyses (see Table C-35) and the best, low, and high exposure and µg/kg-day dose estimates (see Table C-36) for each of the studies used in EPA’s lung cancer dose-response meta-analysis.

Table C-35 Equations and assumptions for estimating µg/kg-day doses from oral lung cancer studies^a^

Citation (Country) | ADWE (yr) | AAD (yr) | LE, SD (μg/L) | WCR, SD (mL/kg-d) | BW, SD (kg) | DI, SD | BMI, SD (kg/m^2^) | RD, SD (yr) | AGE, SD (yr) | Exposure or dose metric | Equation
Argos et al. (2014); (Bangladesh) | – | – | – | – | 62.5, 8.8 | – | 19.7, 3.15 | – | 37.6, 9.35 | μg total As/g creat. | Table C-2, Eqs. F, G
Chen et al. (2010a); (NE Taiwan) | 42 | 65 | 5, 15 | 34.5, 23.2 | – | 0.65, 0.33 | – | 42, 15 | – | μg/L*yr, CE | Table C-2, Eq. E
Dauphiné et al. (2013); (USA) | 39 | 69 | 2.5, 3.3 | 10.7, 63 | – | 0.05, 0.09 | – | 39, 3.3 | – | μg/L*yr, CE | Table C-2, Eq. E
Ferreccio et al. (2000); (Chile) | 63 | 63 | 2.5, 3.3 | 24.3, 13 | – | 1.00, 0.3 | – | – | – | μg/L, WE | Table C-2, Eq. D
García-Esquinaset al. (2013); (USA) | – | – | – | – | 68, 10 | – | 30.9, 6.3 | – | 56.2, 8 | μg total As/g creat. | Table C-2, Eqs. F, G
Steinmaus et al. (2013); (Chile) | 66 | 66 | 2.5, 3.3 | 1.7, 0.9 (L/d) | 68, 10 | 1.00, 0.3 | – | – | – | μg/d, DD | Table C-2, B

ADWE = average duration of well exposure; AAD = average age at diagnosis; LE = low (outside study) exposure; WCR = water consumption rate; BW = body weight; DI = dietary intake; H = height; RD = reported duration of well exposure; Age = control group average age.

a See Conversion Factor Validation spreadsheet for justifications for individual exposure factors.

Table C-36 Dose-response meta-analysis inputs and estimated effective counts for select lung cancer data sets (oral exposure), with three selected sets of dose values

Data set (reported dose units) | Exposure ranges | Dose values for analysis (avg. daily μg/kg–day)^a^ | | | Raw counts | | | Adjusted OR/RR and 95% CIs | | | Effective counts^b^
Data set (reported dose units) | Exposure ranges | MLE | Low | High | Cases | Controls | Expected | Adj OR | LCL | UCL | Cases | Controls | Expected
Argos et al. (2014); (µg/g urinary iAs)^c^ | 0–132.4 | 1.855 | 1.823 | 1.884 | 23 | – | 23 | 1 | 1 | 1 | 23 | – | 23.00
Argos et al. (2014); (µg/g urinary iAs)^c^ | 132.5–331.9 | 5.320 | 5.235 | 5.400 | 36 | – | 22.1 | 1.63 | 0.96 | 2.75 | 34.96 | – | 21.45
Argos et al. (2014); (µg/g urinary iAs)^c^ | ≥332 | 18.905 | 17.922 | 19.982 | 31 | – | 19.3 | 1.61 | 0.93 | 2.76 | 29.83 | – | 18.53
García-Esquinas et al. (2013); (µg/g urinary iAs) | 0–6.91 | 0.139 | 0.138 | 0.140 | 27 | – | 27 | 1 | 1 | 1 | 27 | – | 27
García-Esquinas et al. (2013); (µg/g urinary iAs) | 6.91–13.32 | 0.284 | 0.283 | 0.289 | 20 | – | 21.3 | 0.94 | 0.51 | 1.72 | 16.91 | – | 17.99
García-Esquinas et al. (2013); (µg/g urinary iAs) | ≥13.32 | 0.584 | 0.569 | 0.599 | 31 | – | 17 | 1.82 | 1 | 3.32 | 17.65 | – | 9.70
Chen et al. (2010a); (µg/L*yr)^c^ | 0–100 | 0.77 | 0.75 | 0.79 | 43 | – | 43 | 1 | 1 | 1 | 43 | – | 43
Chen et al. (2010a); (µg/L*yr)^c^ | 100–1,000 | 0.97 | 0.94 | 0.99 | 32 | – | 49.2 | 0.65 | 0.41 | 1.02 | 32.47 | – | 49.95
Chen et al. (2010a); (µg/L*yr)^c^ | 1,000–5,000 | 2.05 | 1.97 | 2.13 | 51 | – | 56 | 0.91 | 0.6 | 1.36 | 49.21 | – | 54.08
Chen et al. (2010a); (µg/L*yr)^c^ | 5,000–10,000 | 4.66 | 4.40 | 4.95 | 23 | – | 14.4 | 1.6 | 0.96 | 2.65 | 22.81 | – | 14.26
Chen et al. (2010a); (µg/L*yr)^c^ | ≥10,000 | 18.97 | 16.99 | 21.21 | 29 | – | 16.3 | 1.78 | 1.11 | 2.85 | 28.89 | – | 16.23
Dauphiné et al. (2013); (µg/L*yr) | 0–0.1 | 0.11 | 0.09 | 0.12 | 70 | 113 | – | 1 | 1 | 1 | 70 | 57.12 | –
Dauphiné et al. (2013); (µg/L*yr) | 0.11–299 | 0.11 | 0.09 | 0.13 | 114 | 232 | – | 0.75 | 0.48 | 1.15 | 107.3 | 116.73 | –
Dauphiné et al. (2013); (µg/L*yr) | ≥2,400 | 1.99 | 0.34 | 7.02 | 12 | 14 | – | 1.2 | 0.45 | 3.22 | 11.22 | 7.63 | –
Ferreccio et al. (2000); (µg/L) | 0–10 | 1.11 | 1.07 | 1.16 | 9 | 104 | – | 1 | 1 | 1 | 9.00 | 42.81 | –
Ferreccio et al. (2000); (µg/L) | 10–29 | 1.38 | 1.28 | 1.49 | 5 | 39 | – | 1.6 | 0.5 | 5.3 | 5.85 | 17.41 | –
Ferreccio et al. (2000); (µg/L) | 30–49 | 1.80 | 1.62 | 2.00 | 8 | 23 | – | 3.9 | 1.2 | 12.3 | 8.35 | 10.18 | –
Ferreccio et al. (2000); (µg/L) | 50–199 | 3.10 | 2.86 | 3.35 | 50 | 124 | – | 5.2 | 2.3 | 11.7 | 55.48 | 50.74 | –
Ferreccio et al. (2000); (µg/L) | 200–400 | 6.69 | 6.17 | 7.24 | 79 | 129 | – | 8.9 | 4.0 | 19.6 | 96.04 | 51.33 | –
Steinmaus et al. (2013); (µg/day) | 0–41 | 1.26 | 1.23 | 1.29 | 64 | 197 | – | 1 | 1 | 1 | 64 | 98.66 | –
Steinmaus et al. (2013); (µg/day) | 41–136 | 1.99 | 1.93 | 2.05 | 56 | 194 | – | 0.87 | 0.55 | 1.36 | 56.73 | 100.52 | –
Steinmaus et al. (2013); (µg/day) | 137–307 | 3.55 | 3.42 | 3.67 | 76 | 154 | – | 1.24 | 0.78 | 1.98 | 58.75 | 73.04 | –
Steinmaus et al. (2013); (µg/day) | ≥307 | 10.76 | 8.43 | 14.52 | 110 | 95 | – | 3.16 | 1.98 | 5.03 | 99.01 | 48.30 | –

a Sets of dose values derived as per Allen et al. (2020a).

b Effective counts derived as per Allen et al. (2020b).

c Person years of reference group follow up for Argos et al. (2014) and Chen et al. (2010a) were 73386 and 19060, respectively.

##### Summary of lung cancer dose-response meta-analysis results for MLE dose estimates

The settings for the Bayesian dose-response meta-analysis summarized in the Table C-37 were:

- 4 chains, each with iterations = 50,000; warmup = 37,500; thin = 1; Adapt_Delta^30^ = 0.9999
- post-warmup draws per chain = 12,500, total post-warmup draws = 50,000
- β_mean Gamma parameters: a = 0.52 and b = 1.12

This section provides details of the results for the hierarchical dose-response meta-analysis modeling (Table C-37, Figures C-17, and C-20), as well as dose-response plots from non-hierarchical modeling of individual studies (Figures C-19 and C-19). Additional details regarding the hierarchical and non-hierarchical modeling results can be obtained from the arsenic dose-response supplemental files (U.S. EPA, 2025), which are accompanied by an explanatory structured workflow, outline, and variable dictionary (U.S. EPA, 2024b).

Table C-37 Summary of lung cancer (oral exposure) Bayesian analysis output using MLE dose estimates

Study | Parameter^a^ | Mean | Standard error of mean | Standard deviation | 2.50% | 25% | 50% | 75% | 97.50% | Effective N | Rhat
Argos et al. (2014) | b | 0.0164 | 0 | 0.0113 | −0.0041 | 0.0085 | 0.0157 | 0.0237 | 0.0401 | 53521 | 1
Argos et al. (2014) | μ(δ) | 26.9618 | 0.0136 | 3.4747 | 20.7106 | 24.5422 | 26.7753 | 29.1755 | 34.3451 | 65719 | 1
Argos et al. (2014) | OR_RR[1] | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 48717 | 0.9999
Argos et al. (2014) | OR_RR[2] | 1.0708 | 0.0002 | 0.0463 | 0.9826 | 1.0392 | 1.0699 | 1.1015 | 1.1648 | 54310 | 1
Argos et al. (2014) | OR_RR[3] | 1.4745 | 0.0015 | 0.3379 | 0.9092 | 1.2342 | 1.4423 | 1.6787 | 2.2326 | 53737 | 1
García-Esquinas et al. (2013) | b | 0.3542 | 0.0023 | 0.3689 | −0.1957 | 0.1039 | 0.283 | 0.5357 | 1.2711 | 25541 | 1
García-Esquinas et al. (2013) | μ(δ) | 28.6507 | 0.0147 | 3.4294 | 22.3928 | 26.2696 | 28.4852 | 30.8369 | 35.8399 | 54076 | 1
García-Esquinas et al. (2013) | OR_RR[1] | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 50171 | 0.9999
García-Esquinas et al. (2013) | OR_RR[2] | 1.0514 | 0.0003 | 0.0556 | 0.9739 | 1.0141 | 1.0394 | 1.0765 | 1.1935 | 26016 | 1
García-Esquinas et al. (2013) | OR_RR[3] | 1.1848 | 0.0013 | 0.2139 | 0.918 | 1.0464 | 1.1321 | 1.2655 | 1.7506 | 25643 | 1
Chen et al. (2010a) | b | 0.0305 | 0.0001 | 0.0114 | 0.0095 | 0.0223 | 0.0302 | 0.0383 | 0.0532 | 51224 | 1
Chen et al. (2010a) | μ(δ) | 38.7827 | 0.0114 | 2.9345 | 33.2739 | 36.7717 | 38.696 | 40.6983 | 44.7755 | 66061 | 1
Chen et al. (2010a) | OR_RR[1] | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 49177 | 0.9999
Chen et al. (2010a) | OR_RR[2] | 1.0066 | 0 | 0.0023 | 1.0023 | 1.005 | 1.0065 | 1.0081 | 1.011 | 51755 | 1
Chen et al. (2010a) | OR_RR[3] | 1.044 | 0.0001 | 0.0146 | 1.0162 | 1.0338 | 1.0438 | 1.0539 | 1.0731 | 52307 | 1
Chen et al. (2010a) | OR_RR[4] | 1.1483 | 0.0002 | 0.0482 | 1.0567 | 1.1151 | 1.1475 | 1.1805 | 1.2449 | 53191 | 1
Chen et al. (2010a) | OR_RR[5] | 2.0844 | 0.0018 | 0.4181 | 1.3568 | 1.7888 | 2.0533 | 2.3449 | 2.9859 | 53369 | 1
Dauphiné et al. (2013) | b | 0.1332 | 0.0007 | 0.1809 | −0.2182 | 0.0172 | 0.1268 | 0.2455 | 0.5087 | 58365 | 1
Dauphiné et al. (2013) | vlambda[1] | 1.0339 | 0.0033 | 0.5995 | 0.213 | 0.5921 | 0.9219 | 1.3487 | 2.4996 | 32166 | 1.0002
Dauphiné et al. (2013) | vlambda[2] | 1.815 | 0.0059 | 1.0464 | 0.3777 | 1.0436 | 1.6204 | 2.3693 | 4.3642 | 31825 | 1.0002
Dauphiné et al. (2013) | vlambda[3] | 0.1393 | 0.0005 | 0.0922 | 0.0252 | 0.0731 | 0.1181 | 0.1822 | 0.3761 | 31519 | 1.0001
Dauphiné et al. (2013) | OR_RR[1] | 1 | NaN | 0 | 1 | 1 | 1 | 1 | 1 | NaN | NaN
Dauphiné et al. (2013) | OR_RR[2] | 1 | 0 | 0 | 0.9999 | 1 | 1 | 1.0001 | 1.0001 | 57550 | 1
Dauphiné et al. (2013) | OR_RR[3] | 1.4008 | 0.0024 | 0.55 | 0.6438 | 1.0361 | 1.295 | 1.6452 | 2.7689 | 52908 | 1
Ferreccio et al. (2000) | b | 0.5003 | 0.0012 | 0.185 | 0.1476 | 0.3721 | 0.4965 | 0.6244 | 0.8699 | 24587 | 1
Ferreccio et al. (2000) | vlambda[1] | 1.2913 | 0.0043 | 0.6733 | 0.3421 | 0.7993 | 1.169 | 1.6526 | 2.9213 | 24701 | 1.0001
Ferreccio et al. (2000) | vlambda[2] | 0.5657 | 0.0019 | 0.3095 | 0.1441 | 0.3418 | 0.5063 | 0.7247 | 1.3162 | 25258 | 1.0001
Ferreccio et al. (2000) | vlambda[3] | 0.4225 | 0.0015 | 0.2359 | 0.1047 | 0.2526 | 0.3758 | 0.5422 | 1.0122 | 25633 | 1.0001
Ferreccio et al. (2000) | vlambda[4] | 1.6878 | 0.0056 | 0.8742 | 0.4502 | 1.049 | 1.5327 | 2.1638 | 3.7839 | 24773 | 1.0001
Ferreccio et al. (2000) | OR_RR[1] | 1 | NaN | 0 | 1 | 1 | 1 | 1 | 1 | NaN | NaN
Ferreccio et al. (2000) | OR_RR[2] | 1.1606 | 0.0004 | 0.0593 | 1.0463 | 1.1203 | 1.1591 | 1.2 | 1.2797 | 22294 | 1.0001
Ferreccio et al. (2000) | OR_RR[3] | 1.48 | 0.0013 | 0.196 | 1.1249 | 1.344 | 1.4681 | 1.6056 | 1.8947 | 23331 | 1.0001
Ferreccio et al. (2000) | OR_RR[4] | 3.413 | 0.0084 | 1.3859 | 1.4231 | 2.4305 | 3.1666 | 4.1316 | 6.7652 | 27353 | 1.0001
Steinmaus et al. (2013) | b | 0.1043 | 0.0001 | 0.028 | 0.0485 | 0.0852 | 0.1047 | 0.1237 | 0.1576 | 49560 | 1
Steinmaus et al. (2013) | vlambda[1] | 1.2685 | 0.0042 | 0.6438 | 0.3413 | 0.7975 | 1.1629 | 1.6231 | 2.8108 | 23557 | 1.0001
Steinmaus et al. (2013) | vlambda[2] | 1.1877 | 0.0039 | 0.6036 | 0.3179 | 0.7475 | 1.0855 | 1.515 | 2.6294 | 23661 | 1.0001
Steinmaus et al. (2013) | vlambda[3] | 0.9218 | 0.0031 | 0.4697 | 0.2457 | 0.5782 | 0.8421 | 1.1794 | 2.0417 | 23556 | 1.0001
Steinmaus et al. (2013) | vlambda[4] | 0.6062 | 0.002 | 0.3165 | 0.1597 | 0.3759 | 0.5493 | 0.775 | 1.3723 | 24009 | 1.0001
Steinmaus et al. (2013) | OR_RR[1] | 1 | NaN | 0 | 1 | 1 | 1 | 1 | 1 | NaN | NaN
Steinmaus et al. (2013) | OR_RR[2] | 1.089 | 0.0001 | 0.019 | 1.0525 | 1.0762 | 1.0887 | 1.1016 | 1.1269 | 50694 | 1
Steinmaus et al. (2013) | OR_RR[3] | 1.3196 | 0.0003 | 0.0696 | 1.1902 | 1.2715 | 1.3169 | 1.3648 | 1.4621 | 50227 | 1
Steinmaus et al. (2013) | OR_RR[4] | 3.5343 | 0.0035 | 0.7729 | 2.2766 | 2.9895 | 3.445 | 3.9831 | 5.2839 | 48132 | 1
Pooled β_mean | | 0.1543 | 0.001 | 0.1329 | 0.0011 | 0.055 | 0.126 | 0.219 | 0.4857 | 16736 | 1.0002
β_sigma | | 0.3172 | 0.0017 | 0.2117 | 0.0704 | 0.1812 | 0.2678 | 0.3925 | 0.856 | 15133 | 1.0003
Power | | 1.0959 | 0.0005 | 0.093 | 1.0026 | 1.029 | 1.0684 | 1.1341 | 1.3387 | 35346 | 1

a The indices, e.g., OR[i] refer to the ith group in the study. The lambda values that characterize the proportion of the control population in each dose-range are computed by vlambda[i]/sum(vlambda[j]) for all i,j in the range appropriate for each study.

For each parameter, n_eff is a crude measure of effective sample size, and Rhat is the potential scale reduction factor on split chains (at convergence, Rhat = 1).

Figure C-17 Posterior distributions for lung cancer pooled (bmean) and data-set-specific (b) logistic slope parameters, using best dose estimates

95% Credible intervals are highlighted.

Figure C-18 Non-hierarchical dose response curves for individual lung cancer studies

Figure C-19 Non-hierarchical dose response curves for Ferreccio et al. (2000), where doses were dropped to improve fit

Figure C-20 Hierarchical dose response curves for individual lung cancer studies

##### Model fit/Convergence for lung cancer dose-response meta-analysis

Overall, the Stan^®^ software used to perform the dose-response meta-analysis modeling indicates model fit/convergence (when including all studies and in the sub analyses) was good for the lung cancer outcomes. An indicator of model convergence the Stan software provides is the number of divergent transitions in the Hamiltonian Markov chain.^31^ The software reported no divergent transitions for the post-warmup iterations for the EPA lung cancer dose-response meta-analysis.

##### Lung cancer sensitivity analyses

EPA has examined the sensitivity of the estimates of the association between oral iAs exposure and lung cancer for nine sources of uncertainty, as follows: (1) characterization of the exposure levels used for the dose-response modeling, (2) the choice of data sets, (3) the assumption that the general U.S. population is not appreciably exposed to iAs via inhalation, (4) consideration of a “high-end” estimate for the U.S. background iAs exposure level, (5) considerations of alternative gamma prior distributions for the pooled slope parameter, (6) the use of urine biomarker studies (if available) in the dose-response meta-analysis, (7) the calculation of the cancer slope factor with varying numbers of doses, (8) the use of a prior for the pooled slope that allows negative values, and (9) use of the logistic-power model vs. the logistic model. Note, for sensitivity analyses (1–2) and (5–6) the pooled slope parameters were estimated using the logistic model with the power parameter set to 1.0959 (i.e., not estimated via MCMC sampling) as to facilitate direct comparison of pooled logistic slopes. To minimize computational burden, different MCMC settings were used than the main analysis: 25,000 iterations, 75% warm-up ratio, thin = 1. Consequently, the MLE results presented in Table C-38 are very similar, but not exactly equal to the main analysis MLE results. As such, the results of sensitivity analyses (1–2) and (5–6) should be compared to the MLE results in Table C-38. Sensitivity analyses (3–4) and (7–9) involved modeling and then calculation of lifetime extra risks for comparison, therefore, the results of these sensitivity analyses can be compared to the main analysis.

The sources of uncertainty related to dose metric values are themselves broken down into two components. The first arises because of the need to estimate a mean value for the dose groups reported in terms of ranges of values (in whatever exposure metric). The second relates to conversion of those mean exposure values to a consistent set of units across studies, those units being average daily μg/kg–day. The methods used to characterize those uncertainties are described in Allen et al. (2020a). Table C-38 below summarizes the 95% confidence intervals for the dose-response meta-analysis pooled b value and extra risk values for bladder cancer for the MLE, “low,” and “high” iAs dose estimates shown in Table C-36. Note that, while the “low” dose estimates provide the largest pooled slope estimates, the mean pooled slope for the “low” dose estimate is only 31% higher than the mean slope for the MLE dose estimates, and the 95th upper bound for the “low” estimate is only 34% higher than the MLE estimate, indicating that the analysis was relatively insensitive to the uncertainties associated with dose characterization.

With respect to sensitivity of the estimates to the choice of dataset, note that the dose-response meta-analysis approach avoids the issue of study selection by pooling the results of all the datasets. Nevertheless, it is of interest to determine how influential each of those studies are on the estimate of the pooled risk. That sensitivity has been investigated by computing the pooled slope when each of the data sets is iteratively excluded from the analysis (i.e., a leave-one-out analysis). Table C-39 lists the pooled and study-specific mean b values when one study is iteratively left out of the analysis. As can be seen, the greatest decrease (65%) is observed when the dataset from Ferreccio et al. (2000) is excluded, and the greatest increase (35%) is observed when the dataset from Argos et al. (2014) is excluded. The dose-response meta-analysis for lung cancer did include one study, Argos et al. (2014), conducted in a Bangladeshi population. This study failed to address the potential for betel nut consumption confounding the observed association between arsenic exposure and lung cancer. Considering that excluding this study only increased the observed pooled slope value by 35%, it does not appear that inclusion of studies that fail to consider betel nut consumption have an oversized impact on modeling results.

Table C-38 Pooled mean b from dose-response meta-analysis of lung cancer studies using MLE, “low,” and “high” dose estimates

| Pooled slope - low dose estimates | Pooled slope - MLE (MLE) dose estimates | Pooled slope - high dose estimates
5% | 0.0042 | 0.0037 | 0.0030
Mean | 0.1989 | 0.1522 | 0.1161
95% | 0.5326 | 0.3985 | 0.3241

Although inhalation of inorganic arsenic is not considered a primary route of exposure for the general public, the World Health Organization (WHO) estimates that background exposure may range from 0.02 to 0.6 μg/day in areas without substantial arsenic emissions from anthropogenic sources. Assuming an average body weight of 70 kg, this corresponds to daily intake values of 2.9 × 10⁻^4^ μg/kg-day to 8.6 × 10⁻^3^ μg/kg-day. The third sensitivity analysis involved two extra lifetable analyses wherein background inhalation components of either 4.4 × 10⁻^3^ μg/kg-day (corresponding to the midpoint of the range of reported background iAs concentrations), or 8.6 × 10⁻^3^ μg/kg-day (corresponding to the upper limit of background concentrations) were added to the original background estimate of exposure due to dietary and drinking water sources (i.e., 0.0365 μg/kg-day). Incorporation of inhalation exposures in the background estimate of total exposure also did not result in appreciably different estimates of extra risk. By definition, as the estimate of background exposure increased in the lifetable analysis, calculated extra risks must correspondingly decrease. Thus, at a 0.13 μg/kg-day dose (approximately equal to a 10 μg/L iAs lifetime drinking water exposure), when the assumed background exposure was either 0.0409 μg/kg-day or 0.0451 μg/kg-day, extra risks decreased to 1.004 × 10⁻^3^ or 1.003 × 10⁻^3^, compared to 1.005 × 10⁻^3^ when no inhalation component was included in the background estimate of exposure. This corresponds to 0.1% and 0.2% decreases in extra risk, respectively. Changes in lifetime extra risk were slightly larger (~0.4% decrease) at the assumed background exposure level of 0.0365 μg/kg–day: 2.55 × 10⁻^4^ for both the low and high inhalation scenarios versus 2.56 × 10⁻^4^ for the main analysis.

Table C-39 Results of the leave-one-out analysis for oral lung cancer datasets using the MLE dose estimate

Study left out | Pooled^a^ | Argos et al. (2014) | García-Esquinas et al. (2013) | Chen et al. (2010a) | Dauphiné et al. (2013) | Ferreccio et al. (2000) | Steinmaus et al. (2013)
Argos et al. (2014) | 0.2050 (0.0046–0.5331) | -- | 0.4800 (−0.0979–1.3152) | 0.0293 (0.0154–0.0427) | 0.1482 (−0.1648–0.4690) | 0.5413 (0.2769–0.8026) | 0.1016 (0.0730–0.1308)
García-Esquinas et al. (2013) | 0.1243 (0.0024–0.3330) | 0.0158 (−0.0005–0.0317) | -- | 0.0293 (0.0152–0.0426) | 0.1213 (−0.1551–0.4149) | 0.4701 (0.1815–0.7477) | 0.1013 (0.0725–0.1306)
Chen et al. (2010a) | 0.2029 (0.0043–0.5284) | 0.0158 (−0.0009–0.0317) | 0.4838 (−0.0944–1.2982) | -- | 0.1487 (−0.1695–0.4671) | 0.5453 (0.2842–0.8026) | 0.1016 (0.0728–0.1306)
Dauphiné et al. (2013) | 0.1760 (0.0035–0.4894) | 0.0157 (−0.0012–0.0317) | 0.4438 (−0.1093–1.2805) | 0.0293 (0.0154–0.0426) | -- | 0.5283 (0.2552–0.7935) | 0.1014 (0.0732–0.1304)
Ferreccio et al. (2000) | 0.0523 (0.0015–0.1388) | 0.0165 (0.0000–0.0323) | 0.0879 (−0.0694–0.3439) | 0.0296 (0.0158–0.0428) | 0.0609 (−0.0729–0.2299) | -- | 0.0952 (0.0653–0.1253)
Steinmaus et al. (2013) | 0.1940 (0.0034–0.5251) | 0.0157 (−0.0008–0.0317) | 0.4813 (−0.1030–1.3090) | 0.0293 (0.0153–0.0426) | 0.1434 (−0.1753–0.4717) | 0.5444 (0.2862–0.8041) | --

a Pooled estimate using all studies was 0.1522 (0.0037−0.3985) (see Table C-38).

Currently, the assessment uses an assumed background iAs exposure level of 0.0365 µg/kg-day based on a median background dietary exposure level of 0.02 µg iAs/kg-day (Xue et al., 2010) and 0.0165 µg iAs/kg-day from drinking water (estimated from the median U.S. Country average inorganic arsenic drinking water concentration [1.5 μg/L] from USGS data (Mendez et al., 2017) multiplied by the average water intake rate in the U.S. population of 0.011 L/kg-day [U.S. EPA (2019), Table 3-1, “All Ages”]). However, there is some uncertainty in the determination of this background exposure level and different values for the dietary and drinking water components of the estimate could have been used. For example, the mean dietary exposure level of 0.05 µg iAs/kg-day from Xue et al. (2010) could have been used, as well has a higher estimate of drinking water exposure of 0.06 µg iAs/kg-day, sourced from Mantha et al. (2016). Using this “high-end” estimate of 0.11 µg iAs/kg-day for the background iAs exposure only decreases the mean lifetime extra risk at the drinking water standard of 10 µg/L (corresponding to 0.13 µg/kg-day daily intake) 1.8%, thus indicating that the lifetable methods used are relatively insensitive to the estimates of U.S. background iAs exposure.

The assumption of different Gamma prior distributions for β_mean did not result in large differences in the posterior distributions of the β_mean parameter (see Table C-40). Interestingly, the alternative prior sensitivity results indicated that, for the present set of studies used in this case-example, the results of the dose-response meta-analysis are rather insensitive to assumptions on the gamma distribution prior. For example, using priors that differed with respect to the 1st percentile (i.e., 1.00001–20 and 1.001–20) resulted in the greatest differences in the mean of the posterior distribution relative to the original prior. This is due to the characteristics of the Gamma distribution, in which the greatest density with respect to probability of response is close to zero. So, when using the 1.00001–20 prior, the corresponding posterior mean distribution was approximately 9.5% lower than the results with the original prior because the 1st percentile is assumed to be ten times lower than for the original prior. Correspondingly, the 1.001–20 prior resulted in a posterior mean distribution approximately 15.1% higher than the original prior. Alternate Gamma prior distributions that differed with respect to the 99th percentile also did not differ greatly from the results using the original prior: using a prior with an upper bound of 10 (i.e., 50% lower than the original) resulted in a posterior mean approximately 2.7% lower and using a prior with an upper bound of 30 (i.e., 50% higher than the original) resulted in a posterior mean less than 1% higher. This broadly indicates that the results of the analysis are heavily influenced by the actual data being modeled and are not inappropriately driven by the prior assumptions of the Bayesian modeling.

Table C-40 Posterior β_mean distribution values resulting from various prior Gamma distributions

Alternative Gamma prior | 5th percentile | Mean | 95th percentile | % Mean difference
1.00001–20; (a = 0.41, b = 1.01) | 0.0010 | 0.1376 | 0.3772 | –9.5%
1.0001–10; (a = 0.54, b = 1.49) | 0.0040 | 0.1482 | 0.3862 | −2.7%
1.0001–30; (a = 0.51, b = 0.99) | 0.0035 | 0.1535 | 0.4014 | 0.6%
1.001–20; (a = 0.71, b = 1.3) | 0.0133 | 0.1752 | 0.4244 | 15.1%
Original Prior(1.0001–20); (a = 0.52, b = 1.12) | 0.0037 | 0.1522 | 0.3985 | –

The outcome of the meta-analysis was sensitive to whether or not urinary biomarker studies were included in the modeling set. For lung cancer, there were only two urinary biomarker studies included the in-modeling set, Argos et al. (2014) and García-Esquinas et al. (2013). As can be seen in Table C-39, when these studies are left out individually, the mean estimate of the logistic slope increases 35% to 0.2050 when Argos et al. (2014) is excluded and decreases 18% to 0.1243 when García-Esquinas et al. (2013) is excluded. When both of the urine studies are excluded, the mean logistic slope estimate increases to 0.1668, a 9.6% increase over the mean logistic slope estimate of 0.1522 when all studies are included in the dose-response meta-analysis.

Next was the consideration of whether the estimation of the cancer slope factor was influenced by the number of risk-at-a-dose values used to characterize the linear trendline. When estimating the cancer slope factor as the linear slope from 0 to 0.2 µg/kg-day using 21 risk-at-a-dose values (i.e., intervals of 0.01 µg/kg-day), a value of 2.13 × 10⁻^2^ per µg/kg-day was obtained (see Section 4.3.6 of main assessment). Varying the number of risk-at-a-dose values used to define the cancer slope factor from 11 to 41 resulted in cancer slope factors of 2.14 × 10⁻^2^ per µg/kg-day and 2.13 × 10⁻^2^ per µg/kg-day, respectively. Thus, the number of risk-at-a-dose values used to define the cancer slope factor appeared to have almost no effect on the estimated slope factor.

In the main analysis, the logistic-power model uses a gamma distribution for the prior over the pooled logistic slope parameter (i.e., bmean), reflecting the weight of evidence determination that iAs exposure is causal for the development of lung cancer. The gamma distribution prior has the greatest density of prior weight on bmean values close to zero and inspection of the posterior distribution for this parameter reveals that the distribution still places high weight on small values (reflecting that many study-specific slope distributions place high weight on negative values). To investigate the degree to which the positivity constraint the gamma distribution places on the estimation of the bmean parameter, an alternative analysis was conducted using a normal (N(0,1)) distribution for the bmean parameter. Modeling of the lung cancer data with this normal bmean parameter resulted in posterior distribution of 0.2057 (95%CI: −0.1350, 0.6415). and calculated mean and upper bound lifetime extra risks of 13.6 out of 10,000 and 36.6 out of 10,000 at 0.13 µg/kg-day (compared to 10.1 out of 10,000 and 27.4 out of 10,000 for the main analysis). Thus, while the use of a normal prior distribution for the bmean parameter does result in the posterior distribution spanning zero and returning negative values, the mean and upper bound lifetime extra risks resulting from modeling with this prior results in marginally (~35%) increased risks compared to the main analysis.

Lastly, a sensitivity analysis was conducted to compare lifetime extra risks derived from modeling that used the logistic model instead of the logistic power model. In the main analysis, both models were not used as the logistic model is a degenerate form of the logistic-power model when power = 1. However, use the logistic-power model only resulted in an estimated power parameter = 1.0959, which is very close to a value of 1. Mean and upper bound lifetime extra risks at 0.13 µg/kg-day, using the logistic model, were 13.6 out of 10,000 and 35.1 out of 10,000 (compared to 10.1 out of 10,000 and 27.4 out of 10,000 for the main analysis). This is to be expected as the use of the logistic-power model with power parameter values >1 implies greater curvature in the low dose region compared to the logistic model, resulting in lower lifetime extra risks.

##### Lung cancer lifetime extra risk table

Table C-41 Lung cancer lifetime extra risks for doses 0.005 µg/kg-day to 1.5 µg/kg-day

Dose | Mean | UCL
0.005 | 0.000031 | 0.000091
0.01 | 0.000064 | 0.000186
0.015 | 0.000099 | 0.000284
0.02 | 0.000135 | 0.000383
0.025 | 0.000171 | 0.000482
0.03 | 0.000207 | 0.000584
0.035 | 0.000245 | 0.000686
0.04 | 0.000282 | 0.000789
0.045 | 0.000320 | 0.000892
0.05 | 0.000358 | 0.000997
0.055 | 0.000397 | 0.001102
0.06 | 0.000436 | 0.001208
0.065 | 0.000475 | 0.001314
0.07 | 0.000515 | 0.001420
0.075 | 0.000554 | 0.001527
0.08 | 0.000594 | 0.001637
0.085 | 0.000634 | 0.001745
0.09 | 0.000675 | 0.001853
0.095 | 0.000715 | 0.001961
0.1 | 0.000756 | 0.002072
0.105 | 0.000797 | 0.002183
0.11 | 0.000838 | 0.002293
0.115 | 0.000880 | 0.002405
0.12 | 0.000921 | 0.002517
0.125 | 0.000963 | 0.002628
0.13 | 0.001005 | 0.002742
0.135 | 0.001047 | 0.002855
0.14 | 0.001090 | 0.002971
0.145 | 0.001132 | 0.003086
0.15 | 0.001175 | 0.003199
0.155 | 0.001218 | 0.003315
0.16 | 0.001260 | 0.003430
0.165 | 0.001304 | 0.003544
0.17 | 0.001347 | 0.003660
0.175 | 0.001390 | 0.003777
0.18 | 0.001434 | 0.003895
0.185 | 0.001477 | 0.004014
0.19 | 0.001521 | 0.004130
0.195 | 0.001565 | 0.004248
0.2 | 0.001609 | 0.004368
0.205 | 0.001654 | 0.004489
0.21 | 0.001698 | 0.004611
0.215 | 0.001743 | 0.004734
0.22 | 0.001787 | 0.004854
0.225 | 0.001832 | 0.004975
0.23 | 0.001877 | 0.005097
0.235 | 0.001922 | 0.005218
0.24 | 0.001967 | 0.005339
0.245 | 0.002013 | 0.005462
0.25 | 0.002058 | 0.005586
0.255 | 0.002104 | 0.005708
0.26 | 0.002149 | 0.005830
0.265 | 0.002195 | 0.005952
0.27 | 0.002241 | 0.006077
0.275 | 0.002287 | 0.006204
0.28 | 0.002334 | 0.006328
0.285 | 0.002380 | 0.006452
0.29 | 0.002426 | 0.006579
0.295 | 0.002473 | 0.006707
0.3 | 0.002520 | 0.006832
0.305 | 0.002567 | 0.006960
0.31 | 0.002614 | 0.007089
0.315 | 0.002661 | 0.007213
0.32 | 0.002708 | 0.007343
0.325 | 0.002755 | 0.007467
0.33 | 0.002803 | 0.007597
0.335 | 0.002850 | 0.007725
0.34 | 0.002898 | 0.007852
0.345 | 0.002946 | 0.007979
0.35 | 0.002993 | 0.008107
0.355 | 0.003041 | 0.008233
0.36 | 0.003090 | 0.008365
0.365 | 0.003138 | 0.008495
0.37 | 0.003186 | 0.008625
0.375 | 0.003235 | 0.008753
0.38 | 0.003283 | 0.008885
0.385 | 0.003332 | 0.009015
0.39 | 0.003381 | 0.009147
0.395 | 0.003430 | 0.009280
0.4 | 0.003479 | 0.009416
0.405 | 0.003528 | 0.009550
0.41 | 0.003577 | 0.009685
0.415 | 0.003627 | 0.009816
0.42 | 0.003676 | 0.009949
0.425 | 0.003726 | 0.010086
0.43 | 0.003775 | 0.010218
0.435 | 0.003825 | 0.010350
0.44 | 0.003875 | 0.010482
0.445 | 0.003925 | 0.010618
0.45 | 0.003975 | 0.010751
0.455 | 0.004026 | 0.010891
0.46 | 0.004076 | 0.011028
0.465 | 0.004127 | 0.011165
0.47 | 0.004177 | 0.011305
0.475 | 0.004228 | 0.011446
0.48 | 0.004279 | 0.011583
0.485 | 0.004330 | 0.011727
0.49 | 0.004381 | 0.011863
0.495 | 0.004432 | 0.012008
0.5 | 0.004483 | 0.012151
0.505 | 0.004535 | 0.012290
0.51 | 0.004586 | 0.012431
0.515 | 0.004638 | 0.012570
0.52 | 0.004689 | 0.012713
0.525 | 0.004741 | 0.012855
0.53 | 0.004793 | 0.012995
0.535 | 0.004845 | 0.013135
0.54 | 0.004897 | 0.013276
0.545 | 0.004949 | 0.013420
0.55 | 0.005002 | 0.013562
0.555 | 0.005054 | 0.013709
0.56 | 0.005107 | 0.013853
0.565 | 0.005160 | 0.013997
0.57 | 0.005212 | 0.014142
0.575 | 0.005265 | 0.014284
0.58 | 0.005318 | 0.014435
0.585 | 0.005371 | 0.014583
0.59 | 0.005425 | 0.014732
0.595 | 0.005478 | 0.014891
0.6 | 0.005531 | 0.015035
0.605 | 0.005585 | 0.015182
0.61 | 0.005639 | 0.015328
0.615 | 0.005692 | 0.015477
0.62 | 0.005746 | 0.015626
0.625 | 0.005800 | 0.015773
0.63 | 0.005854 | 0.015921
0.635 | 0.005909 | 0.016071
0.64 | 0.005963 | 0.016223
0.645 | 0.006017 | 0.016374
0.65 | 0.006072 | 0.016520
0.655 | 0.006126 | 0.016668
0.66 | 0.006181 | 0.016817
0.665 | 0.006236 | 0.016968
0.67 | 0.006291 | 0.017120
0.675 | 0.006346 | 0.017273
0.68 | 0.006401 | 0.017424
0.685 | 0.006456 | 0.017583
0.69 | 0.006512 | 0.017743
0.695 | 0.006567 | 0.017894
0.7 | 0.006623 | 0.018048
0.705 | 0.006679 | 0.018203
0.71 | 0.006735 | 0.018356
0.715 | 0.006790 | 0.018506
0.72 | 0.006846 | 0.018661
0.725 | 0.006903 | 0.018822
0.73 | 0.006959 | 0.018980
0.735 | 0.007015 | 0.019138
0.74 | 0.007072 | 0.019295
0.745 | 0.007128 | 0.019458
0.75 | 0.007185 | 0.019616
0.755 | 0.007242 | 0.019776
0.76 | 0.007299 | 0.019936
0.765 | 0.007356 | 0.020097
0.77 | 0.007413 | 0.020255
0.775 | 0.007470 | 0.020415
0.78 | 0.007528 | 0.020573
0.785 | 0.007585 | 0.020733
0.79 | 0.007643 | 0.020889
0.795 | 0.007700 | 0.021052
0.8 | 0.007758 | 0.021214
0.805 | 0.007816 | 0.021374
0.81 | 0.007874 | 0.021532
0.815 | 0.007932 | 0.021694
0.82 | 0.007990 | 0.021854
0.825 | 0.008049 | 0.022014
0.83 | 0.008107 | 0.022185
0.835 | 0.008166 | 0.022348
0.84 | 0.008224 | 0.022511
0.845 | 0.008283 | 0.022680
0.85 | 0.008342 | 0.022843
0.855 | 0.008401 | 0.023012
0.86 | 0.008460 | 0.023180
0.865 | 0.008519 | 0.023343
0.87 | 0.008579 | 0.023506
0.875 | 0.008638 | 0.023671
0.88 | 0.008698 | 0.023851
0.885 | 0.008757 | 0.024013
0.89 | 0.008817 | 0.024179
0.895 | 0.008877 | 0.024340
0.9 | 0.008937 | 0.024511
0.905 | 0.008997 | 0.024681
0.91 | 0.009057 | 0.024849
0.915 | 0.009118 | 0.025023
0.92 | 0.009178 | 0.025188
0.925 | 0.009239 | 0.025367
0.93 | 0.009300 | 0.025531
0.935 | 0.009360 | 0.025707
0.94 | 0.009421 | 0.025884
0.945 | 0.009482 | 0.026055
0.95 | 0.009543 | 0.026226
0.955 | 0.009605 | 0.026393
0.96 | 0.009666 | 0.026566
0.965 | 0.009727 | 0.026735
0.97 | 0.009789 | 0.026908
0.975 | 0.009851 | 0.027080
0.98 | 0.009913 | 0.027251
0.985 | 0.009975 | 0.027426
0.99 | 0.010037 | 0.027613
0.995 | 0.010099 | 0.027795
1 | 0.010161 | 0.027969
1.005 | 0.010223 | 0.028153
1.01 | 0.010286 | 0.028334
1.015 | 0.010348 | 0.028521
1.02 | 0.010411 | 0.028702
1.025 | 0.010474 | 0.028882
1.03 | 0.010537 | 0.029065
1.035 | 0.010600 | 0.029244
1.04 | 0.010663 | 0.029423
1.045 | 0.010727 | 0.029601
1.05 | 0.010790 | 0.029789
1.055 | 0.010853 | 0.029975
1.06 | 0.010917 | 0.030168
1.065 | 0.010981 | 0.030361
1.07 | 0.011045 | 0.030543
1.075 | 0.011109 | 0.030732
1.08 | 0.011173 | 0.030921
1.085 | 0.011237 | 0.031108
1.09 | 0.011301 | 0.031287
1.095 | 0.011366 | 0.031476
1.1 | 0.011430 | 0.031661
1.105 | 0.011495 | 0.031841
1.11 | 0.011560 | 0.032022
1.115 | 0.011625 | 0.032212
1.12 | 0.011690 | 0.032407
1.125 | 0.011755 | 0.032597
1.13 | 0.011820 | 0.032783
1.135 | 0.011886 | 0.032975
1.14 | 0.011951 | 0.033167
1.145 | 0.012017 | 0.033358
1.15 | 0.012083 | 0.033545
1.155 | 0.012149 | 0.033730
1.16 | 0.012215 | 0.033919
1.165 | 0.012281 | 0.034109
1.17 | 0.012347 | 0.034309
1.175 | 0.012413 | 0.034505
1.18 | 0.012480 | 0.034710
1.185 | 0.012546 | 0.034910
1.19 | 0.012613 | 0.035093
1.195 | 0.012680 | 0.035286
1.2 | 0.012747 | 0.035478
1.205 | 0.012814 | 0.035669
1.21 | 0.012881 | 0.035871
1.215 | 0.012948 | 0.036074
1.22 | 0.013016 | 0.036262
1.225 | 0.013083 | 0.036459
1.23 | 0.013151 | 0.036657
1.235 | 0.013219 | 0.036854
1.24 | 0.013287 | 0.037050
1.245 | 0.013355 | 0.037248
1.25 | 0.013423 | 0.037442
1.255 | 0.013491 | 0.037650
1.26 | 0.013560 | 0.037858
1.265 | 0.013628 | 0.038053
1.27 | 0.013697 | 0.038256
1.275 | 0.013765 | 0.038447
1.28 | 0.013834 | 0.038659
1.285 | 0.013903 | 0.038866
1.29 | 0.013972 | 0.039078
1.295 | 0.014042 | 0.039272
1.3 | 0.014111 | 0.039474
1.305 | 0.014181 | 0.039678
1.31 | 0.014250 | 0.039881
1.315 | 0.014320 | 0.040092
1.32 | 0.014390 | 0.040302
1.325 | 0.014460 | 0.040506
1.33 | 0.014530 | 0.040712
1.335 | 0.014600 | 0.040907
1.34 | 0.014671 | 0.041105
1.345 | 0.014741 | 0.041311
1.35 | 0.014812 | 0.041522
1.355 | 0.014882 | 0.041735
1.36 | 0.014953 | 0.041947
1.365 | 0.015024 | 0.042160
1.37 | 0.015095 | 0.042364
1.375 | 0.015167 | 0.042574
1.38 | 0.015238 | 0.042794
1.385 | 0.015309 | 0.043018
1.39 | 0.015381 | 0.043242
1.395 | 0.015453 | 0.043466
1.4 | 0.015525 | 0.043672
1.405 | 0.015597 | 0.043882
1.41 | 0.015669 | 0.044095
1.415 | 0.015741 | 0.044313
1.42 | 0.015813 | 0.044534
1.425 | 0.015886 | 0.044753
1.43 | 0.015959 | 0.044966
1.435 | 0.016031 | 0.045179
1.44 | 0.016104 | 0.045393
1.445 | 0.016177 | 0.045599
1.45 | 0.016250 | 0.045817
1.455 | 0.016324 | 0.046044
1.46 | 0.016397 | 0.046265
1.465 | 0.016471 | 0.046482
1.47 | 0.016544 | 0.046695
1.475 | 0.016618 | 0.046917
1.48 | 0.016692 | 0.047138
1.485 | 0.016766 | 0.047353
1.49 | 0.016840 | 0.047572
1.495 | 0.019902 | 0.069116
1.5 | 0.016989 | 0.048008

Extra risk at dose = 0 is zero by definition.

#### Diabetes

##### Extrapolation to target U.S. population

###### Approximate lifetable lifetime risk approach for diabetes

The posterior distribution for the “pooled” (average) value of the logistic slope parameter, β_mean, was used with a summary value of 40% for the U.S. lifetime probability of developing type 2 diabetes (Gregg et al., 2014)^32^ as the input to a lifetable calculation of the lifetime probability of diabetes as a function of iAs dose (average daily μg/kg–day).

##### Diabetes study and dataset selection

Table C-42 describes the studies selected for the diabetes Bayesian dose-response meta-analysis.

Table C-42 Data sets selected for oral exposure diabetes Bayesian dose-response meta-analysis

Study | Study design | Location | Exposure/dose metric | Estimate of iAs exposure group mean µg/kg-d daily intake range (Estimate of mean U.S. equivalent µg/L drinking water range)^a^ | Health outcome/endpoint | Description | Limitations
Grau-Perez et al. (2017); Table 1, Sens.: Model3+HOMA2-IR | Cohort | United States (Arizona, Oklahoma, North and South Dakota) | Creatinine-adjusted urinary arsenic (µg/g) | 0.066–0.276; (4.18–23.3) | Incident type II diabetes defined as fasting glucose ≥126 mg/dL, self-reported physician diagnosis or self-reported use of insulin or oral diabetes treatment | Medium-sized cohort study (125 diabetes cases, total cohort 1,838) of Native American adults exposed to arsenic via drinking water; urinary total arsenic concentrations were measured from baseline spot urine samples; the analysis controlled for major confounders including smoking | Exposure estimates were based on a one-time baseline urine measurement; relatively short follow-up time
James et al. (2013); Arsenic exposure TWA (µg /L-yr), Final model | Cohort | United States (Colorado) | Drinking water As exposure TWA (µg/L-yr) | 0.135–0.61; (10.5–53.6) | Incident type II diabetes based on self-report (with medical records verification) or fasting glucose test | Large study of randomly selected participants from the San Luis Valley Diabetes Study (SLVDS) (120 cases, 548 total subjects). Estimates of lifetime exposure obtained from residential history linked to geospatial model of predicted iAs in groundwater. Model adjusted for appropriate covariates, including ethnicity, gender, socioeconomic status, education, BMI, smoking, age, alcohol consumption, and physical activity level. | Collected water samples from just 61% of participant residences. Uncertainty associated with geospatial model estimates of arsenic concentrations not well characterized. Fasting glucose test based on WHO standard (≥140 mg/dL) during the time that the SLVDS study was conducted (1984–1998), which differs from the current standard (≥126 mg/dL)
Coronado-González et al. (2007); Table 3, Total arsenic concentrati on levels in urine, Adjusted OR | Case-Control (case-cohort) | Mexico | Creatinine-adjusted urinary arsenic (µg/g creatinine) | 1.37–4.81; (122.7–435.5) | Type II diabetes diagnosed after 2 consecutive fasting blood glucose tests ≥126 mg/dL | Case-cohort study (200 cases, 200 controls) drawn from a larger cross-sectional study. Urinary total arsenic concentrations were measured from baseline spot urine samples; the analysis controlled for major confounders including age, sex, hypertension, family history of diabetes, obesity, and serum lipids. | Smoking was not controlled for explicitly in the logistic regression as a confounding variable; however, the study authors did report that they found “no association between smoking … and the occurrence of diabetes” and that “cases and controls were comparable to the cross-sectional study participants by …. smoking.” Other limitations included lack of temporality, dietary patterns and education was not available, and the possibility that diabetes influences arsenic metabolism and/or concentrations (reverse causation).
Pan et al. (2013); Table 2, Quartiles of arsenic in drinking water (μg/L), Adj. OR, High dose dropped | Case-control | Bangladesh | Drinking water concentrat ion (µg/L) | 1.5–23.20; (134.5–2,107)^b^ | Individuals were defined as type II diabetes cases if their hemoglobin A1c levels were 6.5% or higher | Large case-control study of 84 cases and 827 controls drawn from a larger 1,800 participant case-control study. Drinking water concentrations were obtained for every individual in the study. Model adjusted for appropriate covariates including age, sex, BMI, smoking, and skin lesions. | Sensitivity analyses indicate suggest some selection bias (primary results remained robust in sensitivity analysis), no information on physical activity levels or caloric intakes were available, possibility of some prevalent cases of diabetes included in the analysis, possibility of other nutritional deficiencies which may impact diabetes and/or arsenic toxicity

a Estimated from µg/kg-d ranges (see Table C-44) assuming median U.S. dietary background of 0.02 µg/kg-d (Xue et al., 2010) and mean U.S. water consumption rate of 0.011 L/kg-d (U.S. EPA, 2019; [see Table 3-1, “All Ages”].

b Conversion of Bangladeshi drinking water studies to intake accounted for very high dietary exposure to iAs; therefore, conversion of those Bangladeshi intake levels to U.S. equivalent drinking water concentrations results in very high drinking water concentrations given relatively low levels of dietary exposure in the general U.S. population.

##### Comparison of studies selected for EPA dose-response meta-analysis and studies used in earlier meta-analyses

Wang et al. (2014) performed the only meta-analyses comparable to the EPA dose-response meta-analysis approach in that it involved dose-response meta-analysis modeling of multiple studies of the relation between type II diabetes and inorganic arsenic exposure. It differed from the EPA analysis in that it included cross-sectional studies and studies conducted of the iAs endemic region of SW Taiwan region which, as previously discussed, were excluded from the EPA analysis due to their high degree of uncertainty and questionable relevance. Of the four diabetes studies used in the EPA analysis, two were included in the Wang et al. (2014) analysis (James et al., 2013;Coronado-González et al., 2007), but the two later publications (Pan et al., 2013; Grau-Perez et al., 2017) were not.

##### Diabetes study-specific dose conversions

The study-specific dose conversions and confidence interval estimations were derived in Excel workbooks with the Yasai add-in to do Monte Carlo simulations. Each study required a potentially different set of assumptions for the dose conversions. The study-specific conversion assumptions and results are provided in the Excel files, which are included in the health outcome-specific intake uncertainty folders of the arsenic dose-response supplemental files (U.S. EPA, 2025), which are accompanied by an explanatory structured workflow, outline, and variable dictionary (U.S. EPA, 2024b). The following tables summarize the input equations and assumptions used in the Monte Carlo analyses (see Table C-43) and the MLE, low and high exposure and µg/kg-day dose estimates (see Table C-44) for each of the studies used in EPA’s diabetes dose-response meta-analysis.

Table C-43 Equations and assumptions for estimating µg/kg-day doses from diabetes studies^a^

Citation (country) | ADW E (yr) | AAD (yr) | LE, SD (μg/L) | WCR, SD (mL/kg-d) | BW, SD (kg) | DI, SD | BMI, SD (kg/m2) | RD, SD (yr) | AGE, SD (yr) | Exposure or dose metric | Equation
Coronado-González et al. (2007); (Mexico) | – | – | – | – | 68, 10 | – | 27.4, 4.3 | – | 52.1 13.5 | μg total As/g creat. | Table C-2, Eqs. F, G
Grau-Perez et al. (2017); (USA) | – | – | – | – | 68, 10 | – | 30.9, 6.3 | – | 56.2, 8 | μg total As/g creat. | Table C-2, Eqs. F, G
James et al. (2013); (USA) | 56 | 56 | 2.5, 3.3 | 17, 37 | – | 0.05, 0.09 | – | – | – | μg/L, WE | Table C-2, Eq. D
Pan et al. (2013); (Bangladesh) | 34.1 | 34.1 | 2.5, 3.3 | 61.8, 26.8 | – | 1.44, 0.33 | – | – | – | μg/L, WE | Table C-2, Eq. D

ADWE = average duration of well exposure; AAD = average age at diagnosis; LE = low (outside study) exposure; WCR = water consumption rate; BW = body weight; DI = dietary intake; H = height; RD = reported duration of well exposure; Age = control group average age.

a See Conversion Factor Validation spreadsheet for justifications for individual exposure factors.

Table C-44 Dose-response meta-analysis inputs and estimated effective counts for selected diabetes data sets, with three selected sets of dose values

Data set (reported dose units) | Exposure ranges | Dose values for analysis (avg. daily μg/k–day g)^a^ | | | Raw counts | | | Adjusted OR/RR and 95% CIs | | | Effective counts^b^
Data set (reported dose units) | Exposure ranges | MLE | Low | High | Cases | Controls | Expected | Adj OR | LCL | UCL | Cases | Controls | Expected
Grau-Perez et al. (2017); (μg/g)^c^ | ≤3.3 | 0.066 | 0.066 | 0.066 | 30 | – | 30 | 1 | 1 | 1 | 30 | – | 30
Grau-Perez et al. (2017); (μg/g)^c^ | 3.3–5.8 | 0.129 | 0.128 | 0.133 | 36 | – | 31.6 | 1.14 | 0.67 | 1.95 | 24.43 | – | 21.43
Grau-Perez et al. (2017); (μg/g)^c^ | >5.8 | 0.276 | 0.257 | 0.299 | 59 | – | 28.9 | 2.04 | 1.19 | 3.49 | 23.81 | – | 11.67
James et al. (2013); (μg/L)^c^ | 1–4 | 0.14 | 0.12 | 0.15 | 31 | – | 31 | 1 | 1 | 1 | 31 | – | 31
James et al. (2013); (μg/L)^c^ | 4–8 | 0.18 | 0.16 | 0.21 | 31 | – | 27.9 | 1.11 | 0.82 | 1.95 | 60.32 | – | 54.34
James et al. (2013); (μg/L)^c^ | 8–20 | 0.28 | 0.23 | 0.34 | 36 | – | 25.4 | 1.42 | 0.94 | 2.48 | 34.49 | – | 24.29
James et al. (2013); (μg/L)^c^ | >20 | 0.61 | 0.46 | 0.77 | 43 | – | 27.7 | 1.55 | 1 | 2.51 | 43.75 | – | 28.23
Pan et al. (2013); (μg/L) | ≤1.7 | 1.50 | 1.46 | 1.53 | 11 | – | 11 | 1 | 1 | 1 | 11 | 50.97 | –
Pan et al. (2013); (μg/L) | 1.8–15.5 | 1.80 | 1.76 | 1.85 | 19 | – | 9.9 | 1.92 | 0.84 | 4.35 | 21.6 | 52.13 | –
Pan et al. (2013); (μg/L) | 15.6–170 | 4.48 | 4.16 | 4.86 | 24 | – | 7.8 | 3.07 | 1.38 | 6.85 | 29.42 | 44.4 | –
Pan et al. (2013); (μg/L) | 170–1,050 | 23.20 | 21.15 | 25.50 | 28 | – | 6.2 | 4.51 | 2.01 | 10.09 | – | – | –
Coronado-González et al. (2007); (μg/g) | <63.5 | 1.37 | 1.37 | 1.38 | 36 | 67 | – | 1 | 1 | 1 | 36 | 48.64 | –
Coronado-González et al. (2007); (μg/g) | 63.5–104 | 2.48 | 2.43 | 2.65 | 70 | 67 | – | 2.16 | 1.23 | 3.79 | 76.26 | 47.7 | –
Coronado-González et al. (2007); (μg/g) | >104 | 4.81 | 4.13 | 5.84 | 94 | 66 | – | 2.84 | 1.64 | 4.92 | 102.69 | 48.85 | –

a Sets of dose values derived as per Allen et al. (2020a).

b Effective counts derived as per Allen et al. (2020b).

c Person years of reference group follow up for Grau-Perez and James were 2,590 and 1,301, respectively.

##### Summary of diabetes dose-response meta-analysis results for MLE dose estimates

The settings for the Bayesian dose-response meta-analysis summarized in Table C-45 were:

- 4 chains, each with iterations = 50,000; warmup = 37,500; thin = 1; Adapt_Delta^33^ = 0.9999
- post-warmup draws per chain = 12,500, total post-warmup draws = 50,000
- β_mean Gamma parameters: a = 0.52 and b = 1.12

This section provides details of the results for the hierarchical dose-response meta-analysis modeling (Table C-45, Figures C-21, and C-24), as well as dose-response plots (Figures C-22 and C-23) from non-hierarchical modeling of individual studies. Additional details regarding the hierarchical and non-hierarchical modeling results can be obtained from the arsenic dose-response supplemental files (U.S. EPA, 2025), which are accompanied by an explanatory structured workflow, outline, and variable dictionary (U.S. EPA, 2024b).

Table C-45 Summary of diabetes Bayesian analysis output using MLE dose estimates

Study | Parameter^a^ | Mean | Standard error of mean | Standard deviation | 2.50% | 25% | 50% | 75% | 97.50% | Effective N | Rhat
Grau-Perez et al. (2017); (μg/g) | b | 0.7736 | 0.012 | 0.9825 | −0.1589 | 0.1955 | 0.378 | 1.0011 | 3.6676 | 6707 | 1.0011
Grau-Perez et al. (2017); (μg/g) | μ(δ) | 35.8867 | 0.0357 | 4.6302 | 27.2508 | 32.7169 | 35.7411 | 38.8695 | 45.4231 | 16859 | 1.0003
Grau-Perez et al. (2017); (μg/g) | OR_RR[1] | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 30088 | 0.9999
Grau-Perez et al. (2017); (μg/g) | OR_RR[2] | 1.0437 | 0.0007 | 0.0577 | 0.992 | 1.01 | 1.0208 | 1.055 | 1.2171 | 7117 | 1.0009
Grau-Perez et al. (2017); (μg/g) | OR_RR[3] | 1.1778 | 0.0031 | 0.2632 | 0.9715 | 1.0363 | 1.0745 | 1.2077 | 1.9855 | 7405 | 1.0009
James et al. (2013); (μg/L) | b | 0.4816 | 0.0039 | 0.3675 | −0.0328 | 0.2167 | 0.3842 | 0.6971 | 1.3586 | 8713 | 1.0006
James et al. (2013); (μg/L) | μ(δ) | 35.8548 | 0.0266 | 3.4732 | 29.0387 | 33.5301 | 35.8208 | 38.2019 | 42.7095 | 16987 | 1
James et al. (2013); (μg/L) | OR_RR[1] | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1934 | 0.9999
James et al. (2013); (μg/L) | OR_RR[2] | 1.0205 | 0.0002 | 0.0161 | 0.9987 | 1.0089 | 1.0163 | 1.0295 | 1.0597 | 9219 | 1.0005
James et al. (2013); (μg/L) | OR_RR[3] | 1.0673 | 0.0006 | 0.0538 | 0.9958 | 1.0287 | 1.0525 | 1.0967 | 1.1998 | 9120 | 1.0005
James et al. (2013); (μg/L) | OR_RR[4] | 1.2603 | 0.0024 | 0.2257 | 0.9853 | 1.1022 | 1.1895 | 1.3693 | 1.8419 | 9104 | 1.0005
Pan et al. (2013); (μg/L) | b | 0.2467 | 0.0006 | 0.1013 | 0.0616 | 0.1757 | 0.2423 | 0.3137 | 0.4565 | 26157 | 1
Pan et al. (2013); (μg/L) | μ(δ) | 13.4697 | 0.0159 | 2.6181 | 8.9494 | 11.6075 | 13.2563 | 15.0957 | 19.1949 | 27080 | 0.9999
Pan et al. (2013); (μg/L) | OR_RR[1] | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 30235 | 0.9999
Pan et al. (2013); (μg/L) | OR_RR[2] | 1.0924 | 0.0002 | 0.0344 | 1.0266 | 1.0693 | 1.0916 | 1.1149 | 1.1618 | 25464 | 1
Pan et al. (2013); (μg/L) | OR_RR[3] | 2.6321 | 0.0054 | 0.8638 | 1.3249 | 2.0266 | 2.4996 | 3.0929 | 4.674 | 25799 | 1
Coronado-González et al. (2007); (μg/g) | b | 0.2082 | 0.0004 | 0.0753 | 0.0693 | 0.1539 | 0.206 | 0.2583 | 0.3616 | 30232 | 1.0001
Coronado-González et al. (2007); (μg/g) | vlambda[1] | 0.8968 | 0.0045 | 0.5307 | 0.1842 | 0.5086 | 0.7929 | 1.1661 | 2.2155 | 13785 | 1
Coronado-González et al. (2007); (μg/g) | vlambda[2] | 1.1376 | 0.0057 | 0.666 | 0.234 | 0.6508 | 1.009 | 1.4804 | 2.7787 | 13625 | 1.0001
Coronado-González et al. (2007); (μg/g) | vlambda[3] | 0.947 | 0.0048 | 0.5606 | 0.1944 | 0.5383 | 0.8357 | 1.2351 | 2.3502 | 13653 | 1
Coronado-González et al. (2007); (μg/g) | OR_RR[1] | 1 | NaN | 0 | 1 | 1 | 1 | 1 | 1 | NaN | NaN
Coronado-González et al. (2007); (μg/g) | OR_RR[2] | 1.3186 | 0.0006 | 0.1065 | 1.1239 | 1.2436 | 1.3136 | 1.3875 | 1.5422 | 30691 | 1.0001
Coronado-González et al. (2007); (μg/g) | OR_RR[3] | 2.5235 | 0.0038 | 0.6537 | 1.479 | 2.0575 | 2.4379 | 2.9033 | 4.0239 | 30084 | 1
Pooled β_mean | | 0.3056 | 0.0026 | 0.2802 | 0.0037 | 0.1334 | 0.2415 | 0.383 | 1.0624 | 11852 | 1.0006
β_sigma | | 0.568 | 0.0105 | 0.8085 | 0.0088 | 0.1015 | 0.2885 | 0.7179 | 2.6791 | 5979 | 1.001
Power | | 1.1278 | 0.0008 | 0.1319 | 1.0032 | 1.0379 | 1.0888 | 1.1737 | 1.4754 | 29741 | 1

a The indices, e.g., OR[i] refer to the ith group in the study. The lambda values that characterize the proportion of the control population in each dose-range are computed by vlambda[i]/sum(vlambda[j]) for all i,j in the range appropriate for each study.

For each parameter, n_eff is a crude measure of effective sample size, and Rhat is the potential scale reduction factor on split chains (at convergence, Rhat = 1).

Figure C-21 Posterior distributions for diabetes pooled (bmean) and data-set-specific (b) logistic slope parameters, using MLE dose estimates

95% Credible intervals are highlighted.

Figure C-22 Non-hierarchical dose response curves for individual diabetes studies

Figure C-23 Non-hierarchical dose response curves for Pan et al. (2013), where doses were dropped to improve fit

Figure C-24 Hierarchical dose response curves for individual diabetes studies

##### Model fit/Convergence for diabetes dose-response meta-analysis

The dose-response meta-analysis results shown above for diabetes incidence indicate different β_mean estimates for analyses using all studies, only low-dose studies, and only high-dose studies. Overall, the Stan^®^ software used to perform the dose-response meta-analysis modeling indicates model fit/convergence (when including all studies and in the sub analyses) was good for the diabetes outcomes. An indicator of model convergence the Stan software provides is the number of divergent transitions in the Hamiltonian Markov chain.^34^ The software reported divergence for approximately 0.02% (n = 2) of the post-warmup iterations for the EPA diabetes dose-response meta-analysis. Given the small number of divergent transitions compared to the total number of post warm-up iterations, this was not considered to be evidence of poor model fit. Additionally, the RHat value for all estimated parameters was good (i.e., values very close to 1), further indicating good model fit and performance.

##### Diabetes sensitivity analyses

EPA has examined the sensitivity of the estimates of the association between oral iAs exposure and diabetes for nine sources of uncertainty, as follows: (1) characterization of the exposure levels used for the dose-response modeling, (2) the choice of data sets, (3) the assumption that the general U.S. population is not appreciably exposed to iAs via inhalation, (4) consideration of a “high-end” estimate for the U.S. background iAs exposure level, (5) considerations of alternative gamma prior distributions for the pooled slope parameter, (6) the use of urine biomarker studies (if available) in the dose-response meta-analysis, (7) the calculation of the cancer slope factor with varying numbers of doses, (8) the use of a prior for the pooled slope that allows negative values, and (9) use of the logistic-power model vs. the logistic model. Note, for sensitivity analyses (1–2) and (5–6), the pooled slope parameters were estimated using the logistic model with the power parameter set to 1.1278 (i.e., not estimated via MCMC sampling) as to facilitate direct comparison of pooled logistic slopes. To minimize computational burden, different MCMC settings were used than the main analysis: 25,000 iterations, 75% warm-up ratio, thin = 1. Consequently, the MLE results presented in Table C-46 are very similar, but not exactly equal to the main analysis MLE results. As such, the results of sensitivity analyses (1–2) and (5–6) should be compared to the MLE results in Table C-46. Sensitivity analyses (3–4) and (7–9) involved modeling and then calculation of lifetime extra risks for comparison, therefore, the results of these sensitivity analyses can be compared to the main analysis.

The sources of uncertainty related to dose metric values are themselves broken down into two components. The first arises because of the need to estimate a mean value for the dose groups reported in terms of ranges of values (in whatever exposure metric). The second relates to conversion of those mean exposure values to a consistent set of units across studies, those units being average daily μg/kg–day. The methods used to characterize those uncertainties are described in Allen et al. (2020a). Table C-46 below summarizes the 95% confidence intervals for the dose-response meta-analysis pooled b value and extra risk values for bladder cancer for the MLE, “low,” and “high” iAs dose estimates shown in Table C-44. Note that, while the “low” dose estimates provide the largest pooled slope estimates, the mean pooled slope for the “low” dose estimate is only 20% higher than the mean slope for the MLE dose estimates, and the 95th upper bound for the “low” estimate is only 21% higher than the MLE estimate, indicating that the analysis was relatively insensitive to the uncertainties associated with dose characterization.

Table C-46 Pooled mean b and extra risk estimates from dose-response meta-analysis of diabetes studies using MLE, “low,” and “high” dose estimates

| Pooled slope - low dose estimates | Pooled slope - MLE (MLE) dose estimates | Pooled slope - high dose estimates
5% | 0.0101 | 0.0138 | 0.0102
Mean | 0.3586 | 0.2999 | 0.2516
95% | 1.0058 | 0.8319 | 0.7086

With respect to sensitivity of the estimates to choice of dataset, note that the dose-response meta-analysis approach avoids the issue of study selection by pooling the results of all the datasets. Nevertheless, it is of interest to determine how influential each of those studies are on the estimate of the pooled risk. That sensitivity has been investigated by computing the pooled estimate of risk when each of the data sets is iteratively excluded from the analysis (i.e., a leave-one-out analysis). Table C-47 lists the pooled and study-specific mean b values when one study is iteratively left out of the analysis. As can be seen, the greatest decrease (22%) is observed when the dataset from Grau-Perez et al. (2017) is excluded, and the greatest increase (49%) is observed when the dataset from Coronado-González et al. (2007) is excluded. The dose-response meta-analysis for diabetes did include one study, Pan et al. (2013), conducted in a Bangladeshi population. This study failed to address the potential for betel nut consumption confounding the observed association between arsenic exposure and lung cancer. Considering that excluding this study only increased the observed pooled slope value by 45%, it does not appear that inclusion of studies that fail to consider betel nut consumption have an oversized impact on modeling results.

Table C-47 Results of the leave-one-out analysis for diabetes datasets using the MLE dose estimate

Study left out | Mean b values (5th–95th percentile)
Study left out | Pooled^a^ | Grau-Perez et al. (2017) | James et al. (2013) | Pan et al. (2013) | Coronado-González et al. (2007)
Grau-Perez et al. (2017) | 0.2330 (0.0120–0.5534) | -- | 0.3863 (0.0273–1.0180) | 0.2336 (0.1028–0.3694) | 0.1996 (0.1068–0.2919)
James et al. (2013) | 0.2958 (0.0067–0.9580) | 1.0321 (−0.0477–3.8451) | -- | 0.2348 (0.0958–0.3738) | 0.1968 (0.1029–0.2902)
Pan et al. (2013) | 0.4336 (0.0058–1.3775) | 1.6793 (−0.0045–4.4458) | 0.6852 (0.0628–1.4046) | -- | 0.1969 (0.1014–0.2944)
Coronado-González et al. (2007) | 0.4469 (0.0054–1.3506) | 1.6941 (0.0194–4.4536) | 0.6925 (0.0789–1.3938) | 0.2466 (0.0947–0.3907) | --

a Pooled estimate using all studies was 0.2999 (0.0138–0.8319) (see Table C-46).

Although inhalation of inorganic arsenic is not considered a primary route of exposure for the general public, the World Health Organization (WHO) estimates that background exposure may range from 0.02 to 0.6 μg/day in areas without substantial arsenic emissions from anthropogenic sources. Assuming an average body weight of 70 kg, this corresponds to daily intake values of 2.9 × 10^⁻4^ μg/kg-day to 8.6 × 10⁻^3^ μg/kg-day. The third sensitivity analysis involved two extra lifetable analyses wherein background inhalation components of either 4.4 × 10⁻^3^ μg/kg-day (corresponding to the midpoint of the range of reported background iAs concentrations), or 8.6 × 10⁻^3^ μg/kg-day (corresponding to the upper limit of background concentrations) were added to the original background estimate of exposure due to dietary and drinking water sources (i.e., 0.0365 μg/kg-day). Incorporation of inhalation exposures in the background estimate of total exposure also did not result in appreciably different estimates of extra risk. By definition, as the estimate of background exposure increased in the lifetable analysis, calculated extra risks must correspondingly decrease. Thus, at a 0.13 μg/kg-day iAs dose, when the assumed background exposure was either 0.0409 μg/kg-day or 0.0451 μg/kg-day, extra risks decreased to 1.292 × 10⁻^2^ or 1.290 × 10⁻^2^, compared to 1.293 × 10⁻^2^ when no inhalation component was included in the background estimate of exposure. This corresponds to 0.1% and 0.2% decreases in extra risk, respectively.

Currently, the assessment uses an assumed background iAs exposure level of 0.0365 µg/kg-day based on a median background dietary exposure level of 0.02 µg iAs/kg-day (Xue et al., 2010) and 0.0165 µg iAs/kg-day from drinking water (estimated from the median U.S. Country average inorganic arsenic drinking water concentration [1.5 μg/L] from USGS data (Mendez et al., 2017) multiplied by the average water intake rate in the U.S. population of 0.011 L/kg-day [U.S. EPA (2019), Table 3-1, “All Ages”]). However, there is some uncertainty in the determination of this background exposure level and different values for the dietary and drinking water components of the estimate could have been used. For example, the mean dietary exposure level of 0.05 µg iAs/kg-day from Xue et al. (2010) could have been used, as well has a higher estimate of drinking water exposure of 0.06 µg iAs/kg-day, sourced from Mantha et al. (2016). Using this “high-end” estimate of 0.11 µg iAs/kg-day for the background iAs exposure only decreases the mean lifetime extra risk at the drinking water standard of 10 µg/L (corresponding to 0.13 µg/kg-day daily intake) 2%, thus indicating that the lifetable methods used are relatively insensitive to the estimates of U.S. background iAs exposure.

The assumption of different Gamma prior distributions for β_mean did not result in large differences in the posterior distributions of the β_mean parameter (see Table C-48). Interestingly, the alternative prior sensitivity results indicated that, for the present set of studies used in this case-example, the results of the dose-response meta-analysis are rather insensitive to assumptions on the gamma distribution prior. For example, using priors that differed with respect to the 1st percentile (i.e., 1.00001–20 and 1.001–20) resulted in the greatest differences in the mean of the posterior distribution relative to the original prior. This is due to the characteristics of the Gamma distribution, in which the greatest density with respect to probability of response is close to zero. So, when using the 1.00001–20 prior, the corresponding posterior mean distribution was approximately 9% lower than the results with the original prior because the 1st percentile is assumed to be ten times lower than for the original prior. Correspondingly, the 1.001–20 prior resulted in a posterior mean distribution approximately 7.6% higher than the original prior. Alternate Gamma prior distributions that differed with respect to the 99th percentile also did not differ greatly from the results using the original prior: using a prior with an upper bound of 10 (i.e., 50% lower than the original) resulted in a posterior mean approximately 6.4% lower and using a prior with an upper bound of 30 (i.e., 50% higher than the original) resulted in a posterior mean 2.5% higher. This broadly indicates that the results of the analysis are heavily influenced by the actual data being modeled and are not inappropriately driven by the prior assumptions of the Bayesian modeling.

Table C-48 Posterior β_mean distribution values resulting from various prior Gamma distributions

Alternative Gamma prior | 5th percentile | Mean | 95th percentile | % Mean difference
1.00001–20; (a = 0.41, b = 1.01) | 0.0037 | 0.2730 | 0.7854 | −9%
1.0001–10; (a = 0.54, b = 1.49) | 0.0112 | 0.2815 | 0.7578 | −6.4%
1.0001–30; (a = 0.51, b = 0.99) | 0.0145 | 0.3074 | 0.8608 | 2.5%
1.001–20; (a = 0.71, b = 1.3) | 0.0364 | 0.3227 | 0.8538 | 7.6%
Original Prior(1.0001–20); (a = 0.52, b = 1.12) | 0.0138 | 0.2999 | 0.8319 | --

The next sensitivity analysis investigated to what degree the inclusion of urinary biomarker studies influenced the modeled association between iAs daily intake and type II diabetes. For diabetes, there were only two urinary biomarker studies included in the modeling set, Grau-Perez et al. (2017) and Coronado-González et al. (2007). As can be seen in Table C-47, when these studies are left out individually, the mean estimate of the logistic slope decreases from 0.2999 to 0.2330 when Grau-Perez et al. (2017) is excluded and increases to 0.4469 when Coronado-González et al. (2007) is excluded. This pattern is expected as Grau-Perez is a low-dose study and Coronado-Gonzalez is a moderate- to high-dose study. Given there were only four total studies in the diabetes dose-response meta-analysis, excluding both of these studies was not possible (as that would only leave two studies in the meta-analysis). However, given that the exclusion of the studies individually affected the pooled logistic slope parameter in opposite directions, it is reasonable to expect that excluding both studies would have little impact on the pooled logistic slope.

Next was the consideration of whether the estimation of the polynomial trendline for lifetime extra risk was influenced by the number of risk-at-a-dose values used to characterize the trendline. When estimating the polynomial trendline from 0 to 1.0 µg/kg-day using 11 risk-at-a-dose values (i.e., intervals of 0. 1 µg/kg-day), an equation of y = 0.0508x^2^ + 0.2935x was obtained (see Section 4.3.8 of main assessment). Varying the number of risk-at-a-dose values used to define the polynomial trendline from 11 to 101 resulted in an equation of y = 0.0521x^2^ + 0.2927x µg/kg-day. Deviation of the approximate lifetime extra risks estimated from the polynomial trendlines compared to those calculated from the lifetable was almost equal at low doses: 6.2% overestimation when 101 risk-at-a-dose values were used, and 6.3% overestimation when 11 risk-at-a-dose values were used. Thus, the number of risk-at-a-dose values used to define the polynomial trendline appeared to have limited effect on the estimation of the polynomial equation.

In the main analysis, the logistic-power model uses a gamma distribution for the prior over the pooled logistic slope parameter (i.e., bmean), reflecting the weight of evidence determination that iAs exposure is causal for the development of diabetes. The gamma distribution prior has the greatest density of prior weight on bmean values close to zero and inspection of the posterior distribution for this parameter reveals that the distribution still places high weight on small values (reflecting that many study-specific slope distributions place high weight on negative values). To investigate the degree to which the positivity constraint the gamma distribution places on the estimation of the bmean parameter, an alternative analysis was conducted using a normal (N(0,1)) distribution for the bmean parameter. Modeling of the diabetes data with this normal bmean parameter resulted in posterior distribution of 0.3967 (95%CI: −0.4036, 1.3937) and calculated mean and upper bound lifetime extra risks of 168.5 out of 10,000 and 496.6 out of 10,000 at 0.13 µg/kg-day (compared to 129.3 out of 10,000 and 363.8 out of 10,000 for the main analysis). Thus, while the use of a normal prior distribution for the bmean parameter does result in the posterior distribution spanning zero and returning negative values, the mean and upper bound lifetime extra risks resulting from modeling with this prior results in marginally (~30–36%) increased risks compared to the main analysis.

Lastly, a sensitivity analysis was conducted to compare lifetime extra risks derived from modeling that used the logistic model instead of the logistic power model. In the main analysis, both models were not used as the logistic model is a degenerate form of the logistic-power model when power = 1. However, use the logistic-power model only resulted in an estimated power parameter = 1.0959, which is very close to a value of 1. Mean and upper bound lifetime extra risks at 0.13 µg/kg-day, using the logistic model, were 183.4 out of 10,000 and 458.7 out of 10,000 (compared to 129.3 out of 10,000 and 363.9 out of 10,000 for the main analysis). This is to be expected as the use of the logistic-power model with power parameter values >1 implies greater curvature in the low dose region compared to the logistic model, resulting in lower lifetime extra risks.

##### Diabetes lifetime extra risk table

Table C-49 Diabetes lifetime extra risks for doses 0.065 µg/kg-day to 1.5 µg/kg-day

Dose | Mean | UCL
0.065 | 0.006067 | 0.017245
0.07 | 0.006577 | 0.018671
0.075 | 0.007090 | 0.020079
0.08 | 0.007606 | 0.021516
0.085 | 0.008126 | 0.022986
0.09 | 0.008649 | 0.024409
0.095 | 0.009175 | 0.025893
0.1 | 0.009704 | 0.027377
0.105 | 0.010236 | 0.028836
0.11 | 0.010770 | 0.030341
0.115 | 0.011307 | 0.031853
0.12 | 0.011846 | 0.033419
0.125 | 0.012388 | 0.034876
0.13 | 0.012932 | 0.036377
0.135 | 0.013478 | 0.037898
0.14 | 0.014026 | 0.039432
0.145 | 0.014577 | 0.040971
0.15 | 0.015130 | 0.042525
0.155 | 0.015684 | 0.044010
0.16 | 0.016241 | 0.045531
0.165 | 0.016800 | 0.047049
0.17 | 0.017361 | 0.048597
0.175 | 0.017923 | 0.050212
0.18 | 0.018487 | 0.051846
0.185 | 0.019053 | 0.053453
0.19 | 0.019621 | 0.055053
0.195 | 0.020191 | 0.056630
0.2 | 0.020762 | 0.058291
0.205 | 0.021335 | 0.059838
0.21 | 0.021910 | 0.061406
0.215 | 0.022486 | 0.062982
0.22 | 0.023064 | 0.064580
0.225 | 0.023643 | 0.066181
0.23 | 0.024224 | 0.067777
0.235 | 0.024806 | 0.069398
0.24 | 0.025390 | 0.071030
0.245 | 0.025975 | 0.072643
0.25 | 0.026561 | 0.074319
0.255 | 0.027149 | 0.075985
0.26 | 0.027739 | 0.077644
0.265 | 0.028330 | 0.079263
0.27 | 0.028922 | 0.080948
0.275 | 0.029515 | 0.082634
0.28 | 0.030110 | 0.084214
0.285 | 0.030706 | 0.085890
0.29 | 0.031303 | 0.087587
0.295 | 0.031902 | 0.089183
0.3 | 0.032501 | 0.090786
0.305 | 0.033102 | 0.092554
0.31 | 0.033705 | 0.094281
0.315 | 0.034308 | 0.095896
0.32 | 0.034912 | 0.097664
0.325 | 0.035518 | 0.099319
0.33 | 0.036125 | 0.100977
0.335 | 0.036733 | 0.102580
0.34 | 0.037342 | 0.104257
0.345 | 0.037952 | 0.105929
0.35 | 0.038563 | 0.107630
0.355 | 0.039175 | 0.109334
0.36 | 0.039789 | 0.110998
0.365 | 0.040403 | 0.112752
0.37 | 0.041018 | 0.114416
0.375 | 0.041635 | 0.116157
0.38 | 0.042252 | 0.117922
0.385 | 0.042870 | 0.119536
0.39 | 0.043490 | 0.121308
0.395 | 0.044110 | 0.122999
0.4 | 0.044731 | 0.124749
0.405 | 0.045353 | 0.126474
0.41 | 0.045976 | 0.128147
0.415 | 0.046600 | 0.129837
0.42 | 0.047225 | 0.131536
0.425 | 0.047851 | 0.133270
0.43 | 0.048478 | 0.135121
0.435 | 0.049105 | 0.136826
0.44 | 0.049734 | 0.138557
0.445 | 0.050363 | 0.140266
0.45 | 0.050993 | 0.142058
0.455 | 0.051624 | 0.143812
0.46 | 0.052256 | 0.145581
0.465 | 0.052888 | 0.147293
0.47 | 0.053522 | 0.149016
0.475 | 0.054156 | 0.150820
0.48 | 0.054791 | 0.152687
0.485 | 0.055426 | 0.154564
0.49 | 0.056063 | 0.156276
0.495 | 0.056700 | 0.158123
0.5 | 0.057338 | 0.160001
0.505 | 0.057977 | 0.161838
0.51 | 0.058616 | 0.163646
0.515 | 0.059256 | 0.165399
0.52 | 0.059897 | 0.167203
0.525 | 0.060538 | 0.169154
0.53 | 0.061180 | 0.170965
0.535 | 0.061823 | 0.172766
0.54 | 0.062467 | 0.174618
0.545 | 0.063111 | 0.176423
0.55 | 0.063756 | 0.178282
0.555 | 0.064401 | 0.180128
0.56 | 0.065047 | 0.181842
0.565 | 0.065694 | 0.183729
0.57 | 0.066341 | 0.185426
0.575 | 0.066989 | 0.187182
0.58 | 0.067638 | 0.189019
0.585 | 0.068287 | 0.190866
0.59 | 0.068936 | 0.192677
0.595 | 0.069587 | 0.194482
0.6 | 0.070238 | 0.196282
0.605 | 0.070889 | 0.198100
0.61 | 0.071541 | 0.199768
0.615 | 0.072193 | 0.201505
0.62 | 0.072846 | 0.203268
0.625 | 0.073500 | 0.205120
0.63 | 0.074154 | 0.206836
0.635 | 0.074808 | 0.208769
0.64 | 0.075464 | 0.210547
0.645 | 0.076119 | 0.212298
0.65 | 0.076775 | 0.214104
0.655 | 0.077432 | 0.215918
0.66 | 0.078089 | 0.217637
0.665 | 0.078746 | 0.219460
0.67 | 0.079404 | 0.221336
0.675 | 0.080063 | 0.223111
0.68 | 0.080721 | 0.224924
0.685 | 0.081381 | 0.226780
0.69 | 0.082040 | 0.228541
0.695 | 0.082700 | 0.230380
0.7 | 0.083361 | 0.232140
0.705 | 0.084022 | 0.234085
0.71 | 0.084683 | 0.235957
0.715 | 0.085345 | 0.237836
0.72 | 0.086007 | 0.239660
0.725 | 0.086670 | 0.241389
0.73 | 0.087333 | 0.243225
0.735 | 0.087996 | 0.245091
0.74 | 0.088659 | 0.246869
0.745 | 0.089323 | 0.248661
0.75 | 0.089988 | 0.250454
0.755 | 0.090652 | 0.252172
0.76 | 0.091317 | 0.254085
0.765 | 0.091983 | 0.255888
0.77 | 0.092648 | 0.257911
0.775 | 0.093314 | 0.259759
0.78 | 0.093981 | 0.261549
0.785 | 0.094647 | 0.263312
0.79 | 0.095314 | 0.265068
0.795 | 0.095981 | 0.266838
0.8 | 0.096649 | 0.268637
0.805 | 0.097316 | 0.270627
0.81 | 0.097984 | 0.272324
0.815 | 0.098653 | 0.274170
0.82 | 0.099321 | 0.275932
0.825 | 0.099990 | 0.277694
0.83 | 0.100659 | 0.279469
0.835 | 0.101328 | 0.281554
0.84 | 0.101998 | 0.283283
0.845 | 0.102668 | 0.285012
0.85 | 0.103338 | 0.286929
0.855 | 0.104008 | 0.288790
0.86 | 0.104678 | 0.290543
0.865 | 0.105349 | 0.292327
0.87 | 0.106020 | 0.294182
0.875 | 0.106691 | 0.296054
0.88 | 0.107362 | 0.297858
0.885 | 0.108033 | 0.299692
0.89 | 0.108705 | 0.301476
0.895 | 0.109377 | 0.303257
0.9 | 0.110049 | 0.305050
0.905 | 0.110721 | 0.306833
0.91 | 0.111393 | 0.308746
0.915 | 0.112065 | 0.310671
0.92 | 0.112738 | 0.312443
0.925 | 0.113411 | 0.314420
0.93 | 0.114084 | 0.316280
0.935 | 0.114756 | 0.318223
0.94 | 0.115430 | 0.319999
0.945 | 0.116103 | 0.321856
0.95 | 0.116776 | 0.323701
0.955 | 0.117450 | 0.325523
0.96 | 0.118123 | 0.327366
0.965 | 0.118797 | 0.329181
0.97 | 0.119471 | 0.331140
0.975 | 0.120144 | 0.333158
0.98 | 0.120818 | 0.334884
0.985 | 0.121492 | 0.336703
0.99 | 0.122166 | 0.338556
0.995 | 0.122841 | 0.340411
1 | 0.123515 | 0.342284
1.005 | 0.124189 | 0.344115
1.01 | 0.124864 | 0.345967
1.015 | 0.125538 | 0.347814
1.02 | 0.126212 | 0.349601
1.025 | 0.126887 | 0.351528
1.03 | 0.127561 | 0.353424
1.035 | 0.128236 | 0.355294
1.04 | 0.128911 | 0.357102
1.045 | 0.129585 | 0.358968
1.05 | 0.130260 | 0.360824
1.055 | 0.130935 | 0.362776
1.06 | 0.131609 | 0.364625
1.065 | 0.132284 | 0.366503
1.07 | 0.132959 | 0.368293
1.075 | 0.133633 | 0.370143
1.08 | 0.134308 | 0.371974
1.085 | 0.134983 | 0.373797
1.09 | 0.135658 | 0.375739
1.095 | 0.136332 | 0.377554
1.1 | 0.137007 | 0.379303
1.105 | 0.137681 | 0.381049
1.11 | 0.138356 | 0.382796
1.115 | 0.139031 | 0.384607
1.12 | 0.139705 | 0.386442
1.125 | 0.140380 | 0.388442
1.13 | 0.141054 | 0.390481
1.135 | 0.141728 | 0.392206
1.14 | 0.142403 | 0.393952
1.145 | 0.143077 | 0.395655
1.15 | 0.143751 | 0.397401
1.155 | 0.144425 | 0.399322
1.16 | 0.145099 | 0.401006
1.165 | 0.145773 | 0.402824
1.17 | 0.146447 | 0.404589
1.175 | 0.147121 | 0.406448
1.18 | 0.147795 | 0.408371
1.185 | 0.148469 | 0.410287
1.19 | 0.149142 | 0.411967
1.195 | 0.149816 | 0.413688
1.2 | 0.150489 | 0.415452
1.205 | 0.151162 | 0.417189
1.21 | 0.151836 | 0.418909
1.215 | 0.152509 | 0.420747
1.22 | 0.153182 | 0.422573
1.225 | 0.153854 | 0.424357
1.23 | 0.154527 | 0.426061
1.235 | 0.155200 | 0.427773
1.24 | 0.155872 | 0.429628
1.245 | 0.156545 | 0.431331
1.25 | 0.157217 | 0.432981
1.255 | 0.157889 | 0.434633
1.26 | 0.158561 | 0.436301
1.265 | 0.159233 | 0.438064
1.27 | 0.159904 | 0.439770
1.275 | 0.160576 | 0.441507
1.28 | 0.161247 | 0.443192
1.285 | 0.161918 | 0.444892
1.29 | 0.162589 | 0.446590
1.295 | 0.163260 | 0.448285
1.3 | 0.163931 | 0.450059
1.305 | 0.164601 | 0.451731
1.31 | 0.165272 | 0.453429
1.315 | 0.165942 | 0.455246
1.32 | 0.166612 | 0.457045
1.325 | 0.167282 | 0.458912
1.33 | 0.167951 | 0.460643
1.335 | 0.168621 | 0.462542
1.34 | 0.169290 | 0.464708
1.345 | 0.169959 | 0.466363
1.35 | 0.170628 | 0.468015
1.355 | 0.171297 | 0.469787
1.36 | 0.171965 | 0.471448
1.365 | 0.172633 | 0.473107
1.37 | 0.173301 | 0.474758
1.375 | 0.173969 | 0.476417
1.38 | 0.174637 | 0.478194
1.385 | 0.175304 | 0.480106
1.39 | 0.175972 | 0.481906
1.395 | 0.176639 | 0.483498
1.4 | 0.177305 | 0.485086
1.405 | 0.177972 | 0.486991
1.41 | 0.178638 | 0.488650
1.415 | 0.179304 | 0.490504
1.42 | 0.179970 | 0.492251
1.425 | 0.180636 | 0.494042
1.43 | 0.181301 | 0.495839
1.435 | 0.181966 | 0.497634
1.44 | 0.182631 | 0.499425
1.445 | 0.183296 | 0.501169
1.45 | 0.183960 | 0.502819
1.455 | 0.184625 | 0.504364
1.46 | 0.185288 | 0.506115
1.465 | 0.185952 | 0.507641
1.47 | 0.186615 | 0.509256
1.475 | 0.187279 | 0.510921
1.48 | 0.187942 | 0.512594
1.485 | 0.188604 | 0.514177
1.49 | 0.189266 | 0.515906
1.495 | 0.189929 | 0.517479
1.5 | 0.190590 | 0.519047

Extra risk at dose = 0 is zero by definition.

#### Ischemic Heart Disease (IHD)

##### Extrapolation to target U.S. population

###### Approximate lifetable lifetime risk approach for IHD

For IHD, because lifetables are not available, the logistic slope parameter, β_mean, was used with a summary value for the U.S. lifetime probability of developing IHD^35^ to estimate the lifetime probability developing IHD as a function of iAs dose (average daily μg/kg–day). The methodology is described in Allen et al. (2020b). The exposure scenario used for these extrapolations posits a continuous, full lifetime exposure to a constant iAs dose. The IHD background lifetime probability for the lifetable data used in the analyses is estimated to be 0.4 for IHD (Lloyd-Jones et al., 1999).^36^

##### Study and dataset selection

Table C-50 describes the studies selected for the IHD Bayesian dose-response meta-analysis.

Table C-50 Data sets selected for dose-response analyses of IHD (incidence and fatality) and IHD fatality-only studies

Study (Study type) | Outcome (ascertainment) | Population (exposure/dose metric) | N (follow-up)^b^ | Group mean µg iAs/kg-d range (U.S. equivalent µg/L drinking water range)^c^ | Description | Limitations^d^
IHD (Incidence only or Incidence and Fatal) Studies^a^
Chen et al. (2013); Case-cohort; Table 2, Well arsenic (μg/L), Heart Disease | CVD and IHD incidence; (Clinical exam: ECG and cardiac enzymes; Verbal autopsy, medical records, ICD-10: 100–199) | Matlab, Bangladesh; 18–75 y; 43% men; (µg/L Drinking water) | 1,109; (~6 yr) | 1.8–12.8; (161.8–1161)^e^ | Large case-cohort study of 369 incident fatal and nonfatal cases of CVD, including 148 stroke cases and 211 cases of heart disease, and a sub-cohort of 1,109 subjects randomly selected from the 11,224 participants in Bangladesh Health Effects of Arsenic Longitudinal Study (HEALS). Related iAs in drinking water to cases of CVD, IHD and stroke. 20 wells monitored for 3 yr showed stable As concentrations over time. Controlled for age, sex, BMI, smoking, hypertension, occupation, education, income, diabetes status, hypertension and change in urinary status between visits. | High exposure levels. No follow-up. Only 3 exposure categories. Used arsenic level in index well assessed at baseline. Average duration of index well use was 7.4 yr prior to baseline, accounting for just 20% of each participant’s lifetime. 12% of participants did not exclusively use baseline well. Verbal autopsy may involve some misclassification and non-fatal cases relied on participant visits to field clinic.
James et al. (2015); Case-cohort; Table 4, Arsenic exposure TWA, Final Model | IHD incidence; (Non-fatal: Self-report on yrly follow-up phone calls, and medical record review Fatal: Obituary monitoring and death certificate searches (ICD-9: 410–414)) | Colorado, USA; 20–74 y; 46% male; (µg/L-year Drinking water) | 555; (~<10–14 yr) | 0.2–0.8; (16.4–70.9) | Large study of randomly selected participants from the San Luis Valley Diabetes Study (SLVDS) with a documented IHD event prior to 1998 (96 cases, 459 controls). Estimates of lifetime exposure obtained from residential history linked to geospatial model of predicted iAs in groundwater and drinking-water samples collected from kitchen tap at time of interview. Model adjusted for appropriate covariates, including age, sex, socioeconomic status, BMI, physical activity, smoking status, alcohol consumption, serum lipid levels, and micronutrient intake. | Collected water samples from just 64% of participant residences. Uncertainty associated with geospatial model estimates of arsenic concentrations not well characterized. Authors collected information on intake in order to estimate lifetime dose, but dose estimates did not correlate well with response or with speciated arsenic concentrations in urine samples collected from 1984–1991.
Moon et al. (2013); Prospective cohort; Table 2, Coronary heart disease incidence, Model 2 | CVD and IHD incidence; (Non-fatal: Self-report, clinical follow-up exams, medical records Fatal: Death certificate searches, medical records, informant interviews, ICD-9: 410–414) | Arizona, Oklahoma, and North and South Dakota, USA; 45–74 y; 40% male; (µg/g creatinine, Urine) | 3,575; (~15 yr) | 0.18–0.64; (14.5–56.4) | American Indian participants (ages 45–74 at baseline) from large prospective cohort study of 3,575 U.S. Strong Heart Study American Indians exposed to low levels of iAs. Cohort had relatively high pre-existing rate of diabetes and CVD. Obtained one creatinine adjusted urinary arsenic measurement for all participants, and 3 measurements over 10 yr for a subset of 380 participants. Models adjusted for appropriate covariates age, sex, education, smoking, BMI, LDL cholesterol. Also presented modeling results with diabetes and hypertension treated as covariates. | Relatively high pre-existing rate of diabetes and CVD could have confounded results. Daily intake estimates were based on one urinary sample per individual and individual levels in drinking water were unavailable; temporal reproducibility of urine measurements in subset of 380 participants (3 repeated samples over 10 yr) was 0.64 (95% CI, 0.60 to 0.69).
Wade et al. (2015); Case-control; Table 3, Water arsenic (μg/L), Adjusted OR | IHD incidence^f^; (Nonfatal only: Standard clinical criteria, including angina, ECG, echocardiogram, and cardiac enzymes) | Inner Mongolia, China; 18–70 y; 70% men; (µg/L Drinking water) | 298 cases/275 controls | 0.8–3.0; (70.9–270.9) | Case-control study of adults with CVD and controls from Hang-Hou hospital (298 cases, 275 controls). Water samples collected from primary drinking water source, and subjects assigned a water arsenic exposure based on arsenic concentration of this water source; for shared wells or municipal water, a single sample was used to represent arsenic exposures. Model adjusted for age, sex, education, smoking, BMI, occupation, alcohol use, family history of hypertension, diabetes, or heart disease. | Moderate to high exposure levels. Study only examined non-fatal events.
Wu et al. (2010) | Atherosclerosis; (average systolic blood pressure ≥140 mmHg, average dystolic blood pressure ≥90 mmHg, or a history of hypertension or having taking hypertension medication) | Lanyang basin, Taiwan; (µg/L Drinking water) | 506; (~8 yr) | 0.9-21.27; (80–1926) | Cohort study of 250 incident cases of atherosclerosis in a cohort from the Langyan basin of Taiwan. Estimates of exposure were constructed from a detailed history of residential addresses and duration of artesian well water usage obtained from a structured questionnaire. Model adjusted for appropriate covariates, including age, sex, triglycerides, total cholesterol, and hypertension history. | The study did not include participants who had died of fatal cardiovascular conditions before the scheduled ECCA examination date.
Fatality-only IHD Studies
Chen et al. (2011); Prospective cohort | Fatal CVD and IHD; (Verbal autopsy, medical records, ICD-10: 100–199) | Bangladesh; 18–75 y; 43% men; (µg/L water and µg/g creatinine, urine) | 11746; (~6 yr) | 2.0–15.1; (180–1370) | Health Effects of Arsenic Longitudinal Study (HEALS) of 11,746 participants residing in study area for ≥5 yr. Drinking water iAs concentration calculated from well water samples from 5,966 contiguous wells in the area. Adjusted for age, sex, education, BMI, smoking, change in arsenic between visits. | High exposure levels. Limited follow-up. No details on individual level exposures. Only examined fatal events.
Moon et al. (2013); Prospective cohort | Fatal CVD and IHD; (Fatal: Death certificate searches, medical records, informant interviews, ICD-9: 410–414) | Arizona, Oklahoma, and N and S Dakota, USA; 45–74 y; 40% male; (µg/g creatinine, Urine) | 3,575; (~15 yr) | 0.18–0.64; (14.5–56.4) | See above under “CVD and IHD Incidence Studies”

a Some studies investigated multiple DCS outcomes.

b Number of persons at baseline for cohort studies, number of persons in the sub-cohort at baseline for case-cohort studies and number of cases and non-cases for case-control studies.

c Estimated from µg/kg-d ranges (seeTable C-53) assuming mean U.S. dietary background of 0.02 µg/kg-d (Xue et al., 2010) and mean U.S. water consumption rate of 0.011 L/kg-d (U.S. EPA, 2019; see Table 3-1, “All Ages”).

d Some studies offered models that adjust for hypertension and diabetes. This might be considered a limitation if simpler models are not also provided. EPA prefers models that do not treat these diseases as covariates because of the possibility that they are in the pathological pathway for CVD caused by arsenic.

e Conversion of Bangladeshi drinking water studies to intake accounted for very high dietary exposure to iAs; therefore, conversion of those Bangladeshi intake levels to U.S. equivalent drinking water concentrations results in very high drinking water concentrations given relatively low levels of dietary exposure in the general U.S. population.

f Wade et al. (2015) included 16 cases of cardiomyopathy (<4%), which may not be associated with IHD.

##### Comparison of studies selected for EPA dose-response meta-analysis and studies used in earlier meta-analyses

Moon et al. (2017) updated a prior meta-analysis of CVD health outcomes (Moon et al., 2012), including coronary heart disease (CHD), hereafter referred to as IHD. The Moon et al. (2017) meta-analysis uses high quality studies (see Table C-51) to estimate the relationship between levels of arsenic in drinking water and relative risks for incidence of and fatality from all CVD, IHD, and stroke in the adult general population. They excluded studies of childhood exposures, occupational exposures uncommon in the general population (e.g., arsenic trioxide), case reports or case series, preclinical CVD outcomes, ecological studies (or studies analyzed as group level data), studies with prevalent outcomes, and studies that reported results with fewer than three exposure categories. They identified one prospective cohort study of IHD and stroke (Wang et al., 2005) that reported the results of additional follow-up of two previously described cohorts (Chiou et al., 1997; Chen et al., 1996) from the arsenic-endemic areas of Taiwan combined with a cohort of Taiwan residents exposed to low levels of arsenic in drinking water. They included this study in their systematic review but excluded it from the meta-analysis because the study was not peer reviewed and did not report the number of person-years necessary to calculate the effective number of cases and noncases.^37^

Table C-51 Moon et al. (2017) meta-analysis; arsenic exposure vs. CVD, IHD or stroke^a^

Study | Design | Population | Exposure assessment | Outcome | Adjustment factors
High arsenic in drinking water (At least one exposure group ≥100 µg/L)
Rahman et al. (2014) | Prospective cohort | Matlab, Bangladesh | Individual drinking water (μg/L) | Fatal stroke | Age, sex, education, SES
Chen et al. (2013) | Case-cohort | Araihazar, Bangladesh | TWA household drinking water (µg/L) | Non-fatal and fatal CVD, IHD, and stroke | Age, sex, education, BMI, smoking, hypertension, diabetes, change in arsenic between visits
Chen et al. (2011) | Prospective cohort | Araihazar, Bangladesh | Spot urine (µg/g creatinine) and TWA drinking water (µg/L) | Fatal CVD, IHD, and stroke | Age, sex, education, BMI, smoking, change in arsenic between visits
Sohel et al. (2009) | Prospective cohort | Matlab, Bangladesh | TWA household drinking water (µg/L) | Fatal CVD | Age, sex, education, asset score
Wade et al. (2009) | Retrospective cohort | Inner Mongolia, China | Household drinking water (µg/L) | Fatal CVD, IHD, stroke | Age, sex, education, smoking, alcohol use, farm work
Wang et al. (2005) ^a^ | Prospective cohort, extern. comparison | SW, NE, and low arsenic Taiwan townships | Village, household, and municipal water (µg/L) | Fatal CVD | Age, sex, smoking
Chen et al. (1996) | Prospective cohort | SW Taiwan | Village drinking water | Fatal IHD | Age, sex, smoking, BMI, lipids, hypertension, diabetes
Low-moderate arsenic in drinking water (All exposure groups <100 µg/L)
D’Ippoliti et al. (2015) | Administrative retrospective cohort | Lazio, Italy | Predicted household drinking water (µg/L) | Fatal CVD, IHD, stroke^a^ | Age, calendar period, SES, ceramic industry occupation (individual); smoking sales and radon exposure (municipal)
James et al. (2015) | Prospective case-cohort | Colorado, USA | Household drinking water Predicted TWA household drinking water (µg/L) | Nonfatal and fatal incidence of IHD | Age, sex, income, Hispanic ethnicity, smoking, alcohol use, BMI, sedentary physical activity, family history of IHD, diabetes, LDL cholesterol, TG, HDL cholesterol, folate, selenium
Wade et al. (2015) | Hospital-based case-Control | Inner Mongolia, China | Household drinking water (µg/L) | Nonfatal IHD^b^ | Age, sex, education, smoking, BMI, occupation, alcohol use; family history of hypertension, diabetes, or heart disease
Farzan et al. (2015b) | Prospective case-control | New Hampshire, USA | Toenail (µg/g) | Fatal CVD, IHD, stroke | Age, sex, education, smoking (pack-yr), cancer status (case vs. control)
Moon et al. (2013) | Prospective cohort | Arizona, N Dakota, S Dakota, Oklahoma, USA | Spot urine (µg/g creatinine) | Nonfatal and fatal CVD, IHD, and stroke | Age, sex, education, smoking, BMI, LDL cholesterol

Adapted from Moon et al. (2017).

TWA = time-weighted average, CVD = cardiovascular disease, IHD = ischemic heart disease, LDL = low-density lipoprotein, HDL = high-density lipoprotein, TG = triglycerides, BMI = body mass index, SES = socioeconomic status.

a This study was excluded from the final meta-analysis because it was not peer reviewed and did not report the number of person-years necessary to calculate the effective number of cases and noncases.

b Wade et al. (2015) included 16 cases of cardiomyopathy (<4%), in addition to acute or previous myocardial infarction.

The IHD studies selected by EPA for dose-response meta-analysis (see Section 4.3.1 of the iAs assessment) differ from the studies considered in the Moon et al. (2017) analysis with respect to EPA exclusion of Wang et al. (2005), Wade et al. (2009), Sohel et al. (2009), Rahman et al. (2014), Farzan et al. (2015a), D’Ippoliti et al. (2015), and Chen et al. (1996). Farzan et al. (2015a) was not included due lack of exposure group quantitative results (i.e., analyses treated arsenic as a continuous variable), Chen et al. (1996) is a study of townships in Southwest Taiwan with endemic arseniasis that has experienced extreme iAs exposures not relevant to U.S. populations, Wade et al. (2009) reported incident rate ratios instead of relative risks, D’Ippoliti et al. (2015) did not control for smoking on the individual level, Sohel et al. (2009) did not control for smoking, and Rahman et al. (2014) and Wang et al. (2005) did not investigate IHD endpoints. Further, EPA included Wu et al. (2010) which is a study of atherosclerosis.

While study selection was somewhat similar between the Moon et al. (2017) analysis and the EPA dose-response meta-analysis, methods differed in a number of ways, including the models used, exposure metric modeled, the reference exposure assumed, and the response metric modeled.^38^ However, despite these methodological differences, the conclusions of the two meta-analyses are similar. Although the assumed drinking water reference exposures were different,^39^ both analyses predict a substantial increase in risk of IHD with increasing levels of inorganic iAs exposure.

##### IHD Study-specific dose conversions

The study-specific dose conversions and confidence interval estimations were derived in Excel workbooks with the Yasai add-in to do Monte Carlo simulations. Each study required a potentially different set of assumptions for the dose conversions. The study-specific conversion assumptions and results are provided in the Excel files, which are included in the health outcome-specific intake uncertainty folders of the arsenic dose-response supplemental files (U.S. EPA, 2025), which are accompanied by an explanatory structured workflow, outline, and variable dictionary (U.S. EPA, 2024b). Table C-52 summarizes the input equations and assumptions used in the Monte Carlo analyses and Table C-53 shows the MLE, low and high exposure and µg/kg-day dose estimates for each of the studies used in EPA’s IHD dose-response meta-analysis. Table C-54 presents additional information provided by the authors of Moon et al. (2013) on temporal variability in the urine levels of 386 study participants that was also used in EPA’s Monte Carlo analysis of uncertainty in extrapolating dose from the urine levels reported in the Moon et al. (2013) publication.

Table C-52 Equations and assumptions for estimating µg/kg-day doses from oral IHD studies used in IHD dose-response analyses^a^

Citation (country) | ADWE (yr) | AAD (yr) | LE, SD (μg/L) | WCR, SD (mL/kg-d) | BW, SD (kg) | DI, SD | BMI, SD (kg/m^2^) | RD, SD (yr) | AGE, SD (yr) | Exposure or dose metric | Equation
Chen et al. (2013); (Bangladesh) | 50 | 50 | 2.5, 3.3 | 61.8, 26.8 | – | 1.4, 0.33 | – | – | – | μg/L, WE | Table C-2, Eq. D
James et al. (2015) (USA) | 65 | 65 | 2.5, 3.3 | 17, 37 | – | 0.05, 0.09 | – | – | – | μg/L, WE | Table C-2, Eq. D
Moon et al. (2013) (USA) | – | – | – | – | 68, 10 | – | 30.8, 6.3 | – | 56.2, 8 | μg total As/g creat. | Table C-2, Eqs. F, G
Wade et al. (2015) (China) | 56 | 56 | 2.5, 3.3 | 34.5, 23.2 | – | 0.65, 0.33 | – | – | – | μg/L, WE | Table C-2, Eq. D
Wu et al. (2010); (NE Taiwan) | 65 | 68 | 5, 5 | 34.5, 23.2 | – | 0.65, 0.33 | – | – | | μg/L, WE | Table C-2, Eq. D

ADWE = average duration of well exposure; AAD = average age at diagnosis; LE = low (outside study) exposure; WCR = water consumption rate; BW = body weight; DI = dietary intake; H = height; RD = reported duration of well exposure; Age = control group average age.

a See Conversion Factor Validation spreadsheet for justifications for individual exposure factors.

Table C-53 Dose-response meta-analysis inputs and estimated effective counts for IHD data sets, with three sets of dose values

Data set (exposure units)/person yr^a^ | Exposure ranges (study units) | Doses (μg/kg-d)^b^ | | | Raw counts | | | Adjusted OR/RR and 95% CIs | | | Effective counts^c^
Data set (exposure units)/person yr^a^ | Exposure ranges (study units) | MLE | Low | High | Cases | Control | Expected | adj OR | LCL | UCL | Cases | Control | Expected
Chen et al. (2013); (µg/L)^d^; 2,823 | 7.20 | 1.80 | 1.76 | 1.83 | 61 | – | 61 | 1 | 1 | 1 | 61 | – | 61
Chen et al. (2013); (µg/L)^d^; 2,823 | 59.90 | 4.48 | 4.36 | 4.62 | 72 | – | 61.0 | 1.18 | 0.75 | 1.84 | 27.8 | – | 23.5
Chen et al. (2013); (µg/L)^d^; 2,823 | 222.80 | 12.80 | 12.36 | 13.28 | 75 | – | 48.7 | 1.54 | 1.02 | 2.31 | 36.9 | – | 24.0
James et al. (2015); (µg/L)^d^; 4,806 | 1–20 | 0.20 | 0.19 | 0.22 | 58 | – | 58 | 1 | 1 | 1 | 58 | – | 58
James et al. (2015); (µg/L)^d^; 4,806 | 20–30 | 0.45 | 0.34 | 0.61 | 18 | – | 14.6 | 1.23 | 0.56 | 2.18 | 9.7 | – | 7.9
James et al. (2015); (µg/L)^d^; 4,806 | 30–45 | 0.62 | 0.38 | 1.00 | 16 | – | 7.3 | 2.18 | 1.23 | 4.02 | 13.5 | – | 6.2
James et al. (2015); (µg/L)^d^; 4,806 | 45–88 | 0.82 | 0.31 | 1.77 | 4 | – | 1.3 | 3.1 | 1.1 | 9.11 | 3.7 | – | 1.2
Moon et al. (2013) (µg/g creatinine)^d^; 12,146 | 0–5.8 | 0.18 | 0.17 | 0.18 | 202 | – | 202 | 1 | 1 | 1 | 202 | – | 202
Moon et al. (2013) (µg/g creatinine)^d^; 12,146 | 5.8–9.7 | 0.23 | 0.22 | 0.24 | 206 | – | 196.2 | 1.05 | 0.86 | 1.28 | 187.2 | – | 178.3
Moon et al. (2013) (µg/g creatinine)^d^; 12,146 | 9.7–15.7 | 0.33 | 0.32 | 0.34 | 197 | – | 207.4 | 0.95 | 0.77 | 1.19 | 135.5 | – | 142.6
Moon et al. (2013) (µg/g creatinine)^d^; 12,146 | 15.7–20 | 0.64 | 0.62 | 0.66 | 241 | – | 185.4 | 1.3 | 1.04 | 1.62 | 127.7 | – | 98.2
Wade et al. (2015); (µg/L); Case-control | 0–10 | 0.77 | 0.73 | 0.82 | 168 | 137 | – | 1 | 1 | 1 | 168 | – | 168
Wade et al. (2015); (µg/L); Case-control | 10–39 | 1.28 | 1.20 | 1.36 | 105 | 131 | – | 1.23 | 0.78 | 1.93 | 192.8 | – | 45.7
Wade et al. (2015); (µg/L); Case-control | 40–208 | 2.95 | 1.87 | 4.39 | 15 | 4 | – | 4.05 | 1.1 | 14.99 | 35.6 | – | 2.6
Wu et al. (2010); 809 | 0–10 | 0.90 | 0.76 | 1.04 | 9 | – | 9 | 1 | 1 | 1 | 9 | – | 9
Wu et al. (2010); 809 | 10.1–50 | 1.54 | 1.18 | 1.95 | 9 | – | 3.5 | 2.54 | 0.71 | 9.06 | 3.21 | – | 1.27
Wu et al. (2010); 809 | 50.1–100 | 2.72 | 2.47 | 3.03 | 88 | – | 32.1 | 2.74 | 1.13 | 6.64 | 10.746 | – | 3.93
Wu et al. (2010); 809 | 100.1–300 | 5.68 | 4.94 | 6.49 | 81 | – | 28.7 | 2.82 | 1.16 | 6.87 | 10.55 | – | 3.74
Wu et al. (2010); 809 | >300 | 21.27 | 15.47 | 28.84 | 63 | – | 25.3 | 2.49 | 1.01 | 6.15 | 9.88 | – | 3.97

a Person years of reference group follow up; obtained from Moon et al. (2017), supplemental Table 2.

b Sets of dose values derived as per Allen et al. (2020a).

c Effective counts derived as per Allen et al. (2020b).

d Author reported means without SDs are presented in Moon et al. (2017), supplemental Table 2. These means are used directly in EPA’s analysis. Sensitivity analyses indicate dose estimations do not vary substantially with variance in the exposure group means. Hence, the benefit of using actual reported means is believed to outweigh the benefit of sampling from a presumed distribution.

Table C-54 Strong heart study arsenic concentrations at phase I (1989–1991, baseline) and change over phase II (1993–1995) and phase III (1998–1999), stratified by baseline exposure level groups (Moon et al., 2013)^a^

| N | Phase I concentrations (baseline) | Phase II vs. Phase I change | Phase III vs. Phase I change
<5.8 µg/g | 114 | 4.18 (1.04) | 1.10 (3.12) | 1.65 (4.18)
5.8–9.7 µg/g | 115 | 7.72 (1.17) | −0.53 (4.48) | 0.02 (5.12)
9.8–15.7 µg/g | 69 | 12.65 (1.73) | −2.60 (4.41) | −1.11 (5.82)
>15.7 µg/g | 88 | 24.79 (10.12) | −8.80 (9.56) | −4.63 (13.88)
Overall | 386 | 11.45 (9.22) | −2.32 (6.86) | −0.77 (8.25)

a Data are mean (SD) of urine arsenic concentrations divided by urine creatinine levels, expressed as mg/g. Arsenic concentration is assessed as the sum of iAs, MMA, and DMA.

##### Summary of IHD dose-response meta-analysis results for MLE dose estimates

The settings for the Bayesian dose-response meta-analysis summarized in Table C-55 were:

- 4 chains, each with iterations = 50,000; warmup = 37,50; thin = 1; Adapt_Delta^40^ = 0.9999
- post-warmup draws per chain = 12,500, total post-warmup draws = 50,000
- β_mean Gamma parameters: a = 0.52 and b = 1.12

This section provides details of the results for the hierarchical dose-response meta-analysis modeling (Table C-55, Figures C-25, and C-28), as well as dose-response plots (Figures C-26 and C-27) from non-hierarchical modeling of individual studies. Additional details regarding the hierarchical and non-hierarchical modeling results can be obtained from the arsenic dose-response supplemental files (U.S. EPA, 2025), which are accompanied by an explanatory structured workflow, outline, and variable dictionary (U.S. EPA, 2024b).

Table C-55 Summary of IHD Bayesian analysis output using MLE dose estimates

Study | Parameter^a^ | Mean | Standard error of mean | Standard deviation | 2.50% | 25% | 50% | 75% | 97.50% | Effective N | Rhat
Chen et al. (2013) | b | 0.0298 | 0.0001 | 0.0157 | 0.0027 | 0.0185 | 0.0288 | 0.0402 | 0.0631 | 43908 | 1
Chen et al. (2013) | μ(δ) | 61.8151 | 0.0259 | 5.6021 | 51.5412 | 57.9193 | 61.5944 | 65.4272 | 73.4557 | 46903 | 1
Chen et al. (2013) | OR_RR[1] | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 3746 | 0.9999
Chen et al. (2013) | OR_RR[2] | 1.1018 | 0.0002 | 0.0484 | 1.0104 | 1.0686 | 1.1006 | 1.1335 | 1.2001 | 46183 | 1
Chen et al. (2013) | OR_RR[3] | 1.56 | 0.0014 | 0.2969 | 1.0487 | 1.3506 | 1.5367 | 1.7421 | 2.2105 | 46884 | 1.0001
James et al. (2015); (μg/L) | b | 0.7194 | 0.0046 | 0.5394 | −0.0158 | 0.296 | 0.6152 | 1.0499 | 1.9665 | 13905 | 1.0001
James et al. (2015); (μg/L) | μ(δ) | 61.6857 | 0.0318 | 5.9507 | 50.7206 | 57.553 | 61.4807 | 65.5566 | 74.0301 | 34963 | 1
James et al. (2015); (μg/L) | OR_RR[1] | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 49322 | 0.9999
James et al. (2015); (μg/L) | OR_RR[2] | 1.1982 | 0.0013 | 0.1635 | 0.9962 | 1.0732 | 1.1584 | 1.2859 | 1.6024 | 14770 | 1
James et al. (2015); (μg/L) | OR_RR[3] | 1.3811 | 0.0027 | 0.3378 | 0.9935 | 1.13 | 1.289 | 1.5423 | 2.2461 | 15134 | 1
James et al. (2015); (μg/L) | OR_RR[4] | 1.6521 | 0.0051 | 0.6334 | 0.9902 | 1.201 | 1.4611 | 1.9076 | 3.3376 | 15718 | 1
Moon et al. (2013) | b | 0.4113 | 0.0014 | 0.2154 | 0.0267 | 0.2555 | 0.4053 | 0.5583 | 0.8482 | 22368 | 1.0001
Moon et al. (2013) | μ(δ) | 201.5909 | 0.0462 | 8.3642 | 185.6232 | 195.8207 | 201.4865 | 207.1664 | 218.3858 | 32829 | 1
Moon et al. (2013) | OR_RR[1] | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 49160 | 0.9999
Moon et al. (2013) | OR_RR[2] | 1.0204 | 0.0001 | 0.0109 | 1.0012 | 1.0124 | 1.0199 | 1.0277 | 1.0431 | 23938 | 1
Moon et al. (2013) | OR_RR[3] | 1.0634 | 0.0002 | 0.0343 | 1.0038 | 1.0384 | 1.0617 | 1.0862 | 1.1351 | 23707 | 1
Moon et al. (2013) | OR_RR[4] | 1.2129 | 0.0008 | 0.1208 | 1.0123 | 1.1241 | 1.2038 | 1.2908 | 1.4735 | 23549 | 1.0001
Wu et al. (2010) | b | 0.1564 | 0.0004 | 0.0732 | 0.0239 | 0.1047 | 0.1537 | 0.205 | 0.307 | 39679 | 1
Wu et al. (2010) | μ(δ) | 11.6974 | 0.013 | 2.6682 | 7.2843 | 9.7823 | 11.4214 | 13.2967 | 17.7004 | 41996 | 1
Wu et al. (2010) | OR_RR[1] | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 49981 | 0.9999
Wu et al. (2010) | OR_RR[2] | 1.1174 | 0.0003 | 0.0534 | 1.0183 | 1.0809 | 1.1158 | 1.1526 | 1.2268 | 39781 | 1.0001
Wu et al. (2010) | OR_RR[3] | 1.4004 | 0.001 | 0.1951 | 1.0566 | 1.2645 | 1.3886 | 1.5242 | 1.8187 | 39770 | 1.0001
Wu et al. (2010) | OR_RR[4] | 2.6497 | 0.005 | 1.0108 | 1.1686 | 1.926 | 2.4912 | 3.1976 | 5.0621 | 40340 | 1.0001
Wade et al. (2015) | b | 0.3614 | 0.0011 | 0.2002 | 0.0256 | 0.217 | 0.3447 | 0.4877 | 0.7985 | 32232 | 1
Wade et al. (2015) | vlambda[1] | 1.4809 | 0.0058 | 0.8699 | 0.2941 | 0.8443 | 1.3118 | 1.9335 | 3.6349 | 22764 | 1
Wade et al. (2015) | vlambda[2] | 1.3859 | 0.0055 | 0.8115 | 0.2762 | 0.7897 | 1.2289 | 1.8112 | 3.3732 | 21995 | 1
Wade et al. (2015) | vlambda[3] | 0.1296 | 0.0006 | 0.0964 | 0.0195 | 0.0614 | 0.1049 | 0.1708 | 0.3794 | 22227 | 1
Wade et al. (2015) | OR_RR[1] | 1 | NaN | 0 | 1 | 1 | 1 | 1 | 1 | NaN | NaN
Wade et al. (2015) | OR_RR[2] | 1.2338 | 0.0008 | 0.1393 | 1.015 | 1.133 | 1.2171 | 1.3162 | 1.5496 | 31933 | 1
Wade et al. (2015) | OR_RR[3] | 2.9178 | 0.0095 | 1.763 | 1.0713 | 1.7717 | 2.4601 | 3.5196 | 7.4349 | 34196 | 0.9999
Pooled β_mean | | 0.2602 | 0.0019 | 0.2157 | 0.0028 | 0.1027 | 0.2158 | 0.3626 | 0.8002 | 12623 | 1.0005
β_sigma | | 0.4652 | 0.0038 | 0.392 | 0.061 | 0.2114 | 0.3613 | 0.5978 | 1.463 | 10746 | 1.0003
Power | | 1.1191 | 0.0006 | 0.1133 | 1.0032 | 1.0374 | 1.0869 | 1.1652 | 1.4195 | 41631 | 1

a The indices, e.g., OR[i] refer to the ith group in the study. The lambda values that characterize the proportion of the control population in each dose-range are computed by vlambda[i]/sum(vlambda[j]) for all i,j in the range appropriate for each study.

For each parameter, n_eff is a crude measure of effective sample size, and Rhat is the potential scale reduction factor on split chains (at convergence, Rhat = 1).

Figure C-25 Posterior distributions for IHD pooled (bmean) and data-set-specific (b) logistic slope parameters using MLE dose estimates

95% Credible intervals are highlighted.

Figure C-26 Non-hierarchical dose response curves for individual IHD studies

Figure C-27 Non-hierarchical dose response curve for Wu et al. (2010) with high dose dropped; using MLE dose estimates

Figure C-28 Hierarchical dose response curves for individual IHD studies; using MLE dose estimates

##### Model fit/Convergence for IHD dose-response meta-analysis

Overall, the Stan^®^ software used to perform the dose-response meta-analysis indicates model fit/convergence was good for the IHD outcomes. An indicator of model convergence the Stan software provides is the number of divergent transitions in the Hamiltonian Markov chain.^41^ The software reported divergence for approximately 0.3% (n = 158) of the post-warmup iterations for the EPA IHD dose-response meta-analysis. Although the presence of divergent transitions in the posterior may be of concern, the total number of divergent transitions was small compared to the total number of post-warmup iterations and the location of the divergent transitions appear to be randomly distributed throughout the posterior (see Figure C-29). Thus, there does not appear to be one particular location in the posterior geometry particularly affected by the presence of divergent transitions. Additionally, the RHat value for all estimated parameters was good (i.e., values very close to 1), further indicating good model fit and performance.

Figure C-29 Pairs plots for IHD analysis, divergent transitions marked in red

##### IHD sensitivity analyses

EPA has examined the sensitivity of the estimates of the association between oral iAs exposure and IHD for eight sources of uncertainty, as follows: (1) characterization of the exposure levels used for the dose-response modeling, (2) the choice of data sets, (3) the assumption that the general U.S. population is not appreciably exposed to iAs via inhalation, (4) consideration of a “high-end” estimate for the U.S. background iAs exposure level, (5) considerations of alternative gamma prior distributions for the pooled slope parameter, (6) the calculation of the slope factor with varying numbers of doses, (7) the use of a prior for the pooled slope that allows negative values, and (8) use of the logistic-power model vs. the logistic model. Note, for sensitivity analyses (3–4) and (6–8), the pooled slope parameters were estimated using the logistic model with the power parameter set to 1.1191 (i.e., not estimated via MCMC sampling) as to facilitate direct comparison of pooled logistic slopes. To minimize computational burden, different MCMC settings were used than the main analysis: 25,000 iterations, 75% warm-up ratio, thin = 1. Consequently, the MLE results presented in Table C-56 are very similar, but not exactly equal to the main analysis MLE results. As such, the results of sensitivity analyses (1–2) and (5) should be compared to the MLE results in Table C-56. Sensitivity analyses (3–4) and (6–8) involved modeling and then calculation of lifetime extra risks for comparison, therefore, the results of these sensitivity analyses can be compared to the main analysis.

The sources of uncertainty related to dose metric values are themselves broken down into two components. The first arises because of the need to estimate a mean value for the dose groups reported in terms of ranges of values (in whatever metric). The second relates to conversion of those mean exposure values to a consistent set of units across studies, those units being average daily μg/kg–day. The methods used to characterize those uncertainties are described in Allen et al. (2020a). Table C-56 below summarizes the 95% confidence intervals for the dose-response meta-analysis pooled b values for IHD for the MLE, “low,” and “high” iAs dose estimates shown in Table C-53. Note that, while the “high” dose estimates provide the smallest pooled slope estimates (0.2001 vs. 0.2545), the “low” slope estimates are practically identical to the MLE pooled slope estimates, indicating that the analysis was relatively insensitive to the uncertainties associated with dose characterization.

Table C-56 Pooled mean b and extra risk estimates from dose-response meta-analysis of IHD studies using MLE, “low,” and “high” dose estimates

| Pooled slope - low dose estimates | Pooled slope - MLE (MLE) dose estimates | Pooled slope - high dose estimates
5% | 0.0077 | 0.0085 | 0.01033
Mean | 0.2418 | 0.2545 | 0.2001
95% | 0.6568 | 0.6502 | 0.4525

With respect to sensitivity of the estimates to choice of dataset, note that the dose-response meta-analysis approach avoids the issue of study selection by pooling the results of all the datasets. Nevertheless, it is of interest to determine how influential each of those studies are on the estimate of the pooled risk. That sensitivity has been investigated by computing the pooled estimate of risk when each of the data sets is iteratively excluded from the analysis (i.e., a leave-one-out analysis). Table C-57 lists the pooled and study-specific mean b values when one study is iteratively left out of the analysis. As can be seen, for IHD, the greatest decrease (61%) is observed when the James et al. (2015) study is excluded, and the greatest increase (30%) is observed when either the Chen et al. (2013) or Wu et al. (2010) studies are excluded. The dose-response meta-analysis for IHD did include one study, Chen et al. (2013), conducted in a Bangladeshi population. This study failed to address the potential for betel nut consumption confounding the observed association between arsenic exposure and lung cancer. Considering that excluding this study only increased the observed pooled slope value by 30%, it does not appear that inclusion of studies that fail to consider betel nut consumption have an oversized impact on modeling results. Additionally, the IHD dose-response meta-analysis only included one urine biomarker study (Moon et al., 2013). Given that the pooled logistic slope only decreased approximately 35% when this study was excluded, it does not appear that the analysis was strongly influenced by the inclusion or exclusion of urinary studies. Uncertainty in how seafood consumption and arsenobetaine concentrations in the urine may impact modeling results can be ascertained by considering the pooled slope when the Chen et al. (2013) study is excluded. This is the only urine study that failed to address arsenobetaine when estimating the urinary concentration of total urinary arsenic. Failure to consider arsenobetaine does not appear to greatly impact the results of modeling as excluding the Chen et al. (2013) study only increases the pooled logistic slope by approximately 30%.

Table C-57 Results of the leave-one-out analysis for IHD datasets using the MLE dose estimate

Study left out | Mean b values (5th–95th percentile)
Study left out | Pooled^a^ | Chen et al. (2013) | James et al. (2015) | Moon et al. (2013) | Wu et al. (2010) | Wade et al. (2015)
Chen et al. (2013) | 0.3304 (0.0056–0.8655) | -- | 1.0013 (0.1270–2.0212) | 0.4689 (0.1096–0.8214) | 0.0167 (−0.0053–0.0371) | 0.4030 (0.0935–0.7392)
James et al. (2015) | 0.0985 (0.0017–0.3327) | 0.0275 (0.0069–0.0476) | -- | 0.2344 (−0.0025–0.6375) | 0.0174 (−0.0037–0.0374) | 0.2122 (−0.0008–0.5736)
Moon et al. (2013) | 0.1666 (0.0015–0.6260) | 0.0274 (0.0066–0.0481) | 0.6018 (−0.0133–1.8234) | -- | 0.0171 (−0.0045–0.0371) | 0.2686 (0.0022–0.6685)
Wu et al. (2010) | 0.3300 (0.0066–0.8769) | 0.0281 (0.0071–0.0485) | 0.9837 (0.1134–2.0271) | 0.4658 (0.1076–0.8184) | -- | 0.4020 (0.0891–0.7446)
Wade et al. (2015) | 0.2011 (0.0017–0.7099) | 0.0276 (0.0066–0.0480) | 0.7118 (−0.0058–1.9057) | 0.3483 (0.0055–0.7759) | 0.0172 (−0.0044–0.0374) | --

a Pooled estimate using all studies was 0.2545 (0.0085–0.6502) (see Table C-55).

Although inhalation of inorganic arsenic is not considered a primary route of exposure for the general public, the World Health Organization (WHO) estimates that background exposure may range from 0.02 to 0.6 μg/day in areas without substantial arsenic emissions from anthropogenic sources. Assuming an average body weight of 70 kg, this corresponds to daily intake values of 2.9 × 10⁻^4^ μg/kg-day to 8.6 × 10⁻^3^ μg/kg-day. The third sensitivity analysis involved two extra lifetable analyses wherein background inhalation components of either 4.4 × 10⁻^3^ μg/kg-day (corresponding to the midpoint of the range of reported background iAs concentrations), or 8.6 × 10⁻^3^ μg/kg-day (corresponding to the upper limit of background concentrations) were added to the original background estimate of exposure due to dietary and drinking water sources (i.e., 0.0365 μg/kg-day). Incorporation of inhalation exposures in the background estimate of total exposure also did not result in appreciably different estimates of extra risk. By definition, as the estimate of background exposure increased in the lifetable analysis, calculated extra risks must correspondingly decrease. Thus, for IHD, at a 0.13 μg/kg-day iAs dose (approximately equal to a lifetime drinking water exposure of 10 μg/L), when the assumed background exposure was either 0.0409 μg/kg-day or 0.0451 μg/kg-day, extra risks decreased to 1.099 × 10⁻^2^ or 1.098 × 10⁻^2^, compared to 1.10 × 10⁻^3^ when no inhalation component was included in the background estimate of exposure. This corresponds to 0.1% and 0.2% decreases in extra risk, respectively.

Currently, the assessment uses an assumed background iAs exposure level of 0.0365 µg/kg-day based on a median background dietary exposure level of 0.02 µg iAs/kg-day (Xue et al., 2010) and 0.0165 µg iAs/kg-day from drinking water (estimated from the median U.S. Country average inorganic arsenic drinking water concentration [1.5 μg/L] from USGS data (Mendez et al., 2017) multiplied by the average water intake rate in the U.S. population of 0.011 L/kg-day [U.S. EPA (2019), Table 3-1, “All Ages”]). However, there is some uncertainty in the determination of this background exposure level and different values for the dietary and drinking water components of the estimate could have been used. For example, the mean dietary exposure level of 0.05 µg iAs/kg-day from Xue et al. (2010) could have been used, as well has a higher estimate of drinking water exposure of 0.06 µg iAs/kg-day, sourced from Mantha et al. (2016). Using this “high-end” estimate of 0.11 µg iAs/kg-day for the background iAs exposure only decreases the mean lifetime extra risk at the drinking water standard of 10 µg/L (corresponding to 0.13 µg/kg-day daily intake) 1.7%, thus indicating that the lifetable methods used are relatively insensitive to the estimates of U.S. background iAs exposure.

Finally, the assumption of different Gamma prior distributions for β_mean did not result in large differences in the posterior distributions of the β_mean parameter (see Table C-58). Interestingly, the alternative prior sensitivity results indicated that, for the present set of studies used in this case-example, the results of the dose-response meta-analysis are rather insensitive to assumptions on the gamma distribution prior. For example, using priors that differed with respect to the 1st percentile (i.e., 1.00001–20 and 1.001–20) resulted in the greatest differences in the mean of the posterior distribution relative to the original prior. This is due to the characteristics of the Gamma distribution, in which the greatest density with respect to probability of response is close to zero. So, when using the 1.00001–20 prior, the corresponding posterior mean distribution was approximately 7.8% lower than the results with the original prior because the 1st percentile is assumed to be ten times lower than for the original prior. Correspondingly, the 1.001–20 prior resulted in a posterior mean distribution approximately 12.1% higher than the original prior. Alternate Gamma prior distributions that differed with respect to the 99th percentile also did not differ greatly from the results using the original prior: using a prior with an upper bound of 10 (i.e., 50% lower than the original) resulted in a posterior mean approximately 3.9% lower and using a prior with an upper bound of 30 (i.e., 50% higher than the original) resulted in a posterior mean less than 1.8% higher. This broadly indicates that the results of the analysis are heavily influenced by the actual data being modeled and are not inappropriately driven by the prior assumptions of the Bayesian modeling.

Table C-58 Posterior β_mean distribution values for IHD resulting from various prior Gamma distributions

Alternative Gamma prior | 5th percentile | Mean | 95th percentile | % Mean difference
1.00001–20; (a = 0.41, b = 1.01) | 0.0030 | 0.2348 | 0.6313 | −7.8%
1.0001–10; (a = 0.54, b = 1.49) | 0.0083 | 0.2447 | 0.6199 | −3.9%
1.0001–30; (a = 0.51, b = 0.99) | 0.0094 | 0.2591 | 0.6667 | 1.8%
1.001–20; (a = 0.71, b = 1.3) | 0.0241 | 0.2852 | 0.6825 | 12.1%
Original Prior(1.0001–20); (a = 0.52, b = 1.12) | 0.0085 | 0.2545 | 0.6502 | –

Next was the consideration of whether the estimation of the polynomial trendline for lifetime extra risk was influenced by the number of risk-at-a-dose values used to characterize the trendline. When estimating the polynomial trendline from 0 to 1.0 µg/kg-day using 11 risk-at-a-dose values (i.e., intervals of 0. 1 µg/kg-day), an equation of y = 0.0452x^2^ + 0.2294x was obtained (see Section 4.3.7 of main assessment). Varying the number of risk-at-a-dose values used to define the polynomial trendline from 11 to 101 resulted in an equation of y = 0.0459x^2^ + 0.2289x µg/kg-day. Deviation of the approximate lifetime extra risks estimated from the polynomial trendlines compared to those calculated from the lifetable was almost equal at low doses: 6.2% overestimation when 101 risk-at-a-dose values were used, and 6.3% overestimation when 11 risk-at-a-dose values were used. Thus, the number of risk-at-a-dose values used to define the polynomial trendline appeared to have limited effect on the estimation of the polynomial equation.

In the main analysis, the logistic-power model uses a gamma distribution for the prior over the pooled logistic slope parameter (i.e., bmean), reflecting the weight of evidence determination that iAs exposure is causal for the development of IHD. The gamma distribution prior has the greatest density of prior weight on bmean values close to zero and inspection of the posterior distribution for this parameter reveals that the distribution still places high weight on small values (reflecting that many study-specific slope distributions place high weight on negative values). To investigate the degree to which the positivity constraint the gamma distribution places on the estimation of the bmean parameter, an alternative analysis was conducted using a normal (N(0,1)) distribution for the bmean parameter. Modeling of the IHD data with this normal bmean parameter resulted in posterior distribution of 0.3465 (95%CI: −0.1986, 1.0007) and calculated mean and upper bound lifetime extra risks of 146.9 out of 10,000 and 371.6 out of 10,000 at 0.13 µg/kg-day (compared to 110 out of 10,000 and 290.6 out of 10,000 for the main analysis). Thus, while the use of a normal prior distribution for the bmean parameter does result in the posterior distribution spanning zero and returning negative values, the mean and upper bound lifetime extra risks resulting from modeling with this prior results in marginally (~28%–34%) increased risks compared to the main analysis.

Lastly, a sensitivity analysis was conducted to compare lifetime extra risks derived from modeling that used the logistic model instead of the logistic power model. In the main analysis, both models were not used as the logistic model is a degenerate form of the logistic-power model when power = 1. However, use the logistic-power model only resulted in an estimated power parameter = 1.1191, which is very close to a value of 1. Mean and upper bound lifetime extra risks at 0.13 µg/kg-day, using the logistic model, were 146.7 out of 10,000 and 359.5 out of 10,000 (compared to 110 out of 10,000 and 290.6 out of 10,000 for the main analysis). This is to be expected as the use of the logistic-power model with power parameter values >1 implies greater curvature in the low dose region compared to the logistic model, resulting in lower lifetime extra risks.

##### IHD lifetime extra risk table

Table C-59 IHD lifetime extra risks for doses 0.065 µg/kg-day to 1.5 µg/kg-day

Dose | Mean | UCL
0.065 | 0.005155 | 0.013854
0.07 | 0.005589 | 0.014983
0.075 | 0.006025 | 0.016115
0.08 | 0.006465 | 0.017266
0.085 | 0.006907 | 0.018436
0.09 | 0.007352 | 0.019586
0.095 | 0.007800 | 0.020745
0.1 | 0.008250 | 0.021924
0.105 | 0.008702 | 0.023080
0.11 | 0.009156 | 0.024261
0.115 | 0.009613 | 0.025453
0.12 | 0.010072 | 0.026631
0.125 | 0.010533 | 0.027853
0.13 | 0.010996 | 0.029059
0.135 | 0.011460 | 0.030265
0.14 | 0.011927 | 0.031460
0.145 | 0.012396 | 0.032686
0.15 | 0.012866 | 0.033894
0.155 | 0.013338 | 0.035096
0.16 | 0.013811 | 0.036367
0.165 | 0.014287 | 0.037584
0.17 | 0.014764 | 0.038825
0.175 | 0.015242 | 0.040065
0.18 | 0.015722 | 0.041287
0.185 | 0.016204 | 0.042531
0.19 | 0.016687 | 0.043748
0.195 | 0.017171 | 0.044994
0.2 | 0.017657 | 0.046242
0.205 | 0.018145 | 0.047506
0.21 | 0.018633 | 0.048751
0.215 | 0.019123 | 0.050008
0.22 | 0.019615 | 0.051247
0.225 | 0.020107 | 0.052558
0.23 | 0.020601 | 0.053833
0.235 | 0.021097 | 0.055124
0.24 | 0.021593 | 0.056412
0.245 | 0.022091 | 0.057683
0.25 | 0.022590 | 0.058971
0.255 | 0.023090 | 0.060273
0.26 | 0.023591 | 0.061578
0.265 | 0.024094 | 0.062835
0.27 | 0.024597 | 0.064102
0.275 | 0.025102 | 0.065380
0.28 | 0.025608 | 0.066691
0.285 | 0.026115 | 0.068017
0.29 | 0.026623 | 0.069372
0.295 | 0.027132 | 0.070671
0.3 | 0.027642 | 0.071983
0.305 | 0.028154 | 0.073292
0.31 | 0.028666 | 0.074625
0.315 | 0.029179 | 0.075975
0.32 | 0.029693 | 0.077340
0.325 | 0.030209 | 0.078707
0.33 | 0.030725 | 0.080002
0.335 | 0.031242 | 0.081383
0.34 | 0.031760 | 0.082728
0.345 | 0.032280 | 0.084044
0.35 | 0.032800 | 0.085395
0.355 | 0.033321 | 0.086736
0.36 | 0.033843 | 0.088050
0.365 | 0.034365 | 0.089394
0.37 | 0.034889 | 0.090743
0.375 | 0.035414 | 0.092114
0.38 | 0.035939 | 0.093435
0.385 | 0.036466 | 0.094785
0.39 | 0.036993 | 0.096185
0.395 | 0.037521 | 0.097472
0.4 | 0.038050 | 0.098838
0.405 | 0.038580 | 0.100160
0.41 | 0.039110 | 0.101504
0.415 | 0.039642 | 0.102877
0.42 | 0.040174 | 0.104207
0.425 | 0.040707 | 0.105531
0.43 | 0.041241 | 0.106875
0.435 | 0.041776 | 0.108198
0.44 | 0.042311 | 0.109603
0.445 | 0.042847 | 0.110964
0.45 | 0.043384 | 0.112296
0.455 | 0.043922 | 0.113662
0.46 | 0.044460 | 0.115085
0.465 | 0.044999 | 0.116493
0.47 | 0.045539 | 0.117854
0.475 | 0.046080 | 0.119261
0.48 | 0.046621 | 0.120665
0.485 | 0.047164 | 0.122082
0.49 | 0.047706 | 0.123445
0.495 | 0.048250 | 0.124871
0.5 | 0.048794 | 0.126291
0.505 | 0.049339 | 0.127727
0.51 | 0.049885 | 0.129077
0.515 | 0.050431 | 0.130490
0.52 | 0.050978 | 0.131891
0.525 | 0.051525 | 0.133314
0.53 | 0.052074 | 0.134726
0.535 | 0.052623 | 0.136113
0.54 | 0.053172 | 0.137557
0.545 | 0.053722 | 0.138961
0.55 | 0.054273 | 0.140384
0.555 | 0.054825 | 0.141736
0.56 | 0.055377 | 0.143183
0.565 | 0.055930 | 0.144598
0.57 | 0.056483 | 0.146023
0.575 | 0.057037 | 0.147402
0.58 | 0.057591 | 0.148885
0.585 | 0.058147 | 0.150346
0.59 | 0.058702 | 0.151795
0.595 | 0.059259 | 0.153236
0.6 | 0.059816 | 0.154694
0.605 | 0.060373 | 0.156132
0.61 | 0.060931 | 0.157505
0.615 | 0.061490 | 0.158967
0.62 | 0.062049 | 0.160337
0.625 | 0.062609 | 0.161832
0.63 | 0.063169 | 0.163236
0.635 | 0.063730 | 0.164722
0.64 | 0.064291 | 0.166133
0.645 | 0.064853 | 0.167556
0.65 | 0.065415 | 0.169093
0.655 | 0.065978 | 0.170545
0.66 | 0.066542 | 0.172005
0.665 | 0.067106 | 0.173510
0.67 | 0.067670 | 0.175018
0.675 | 0.068235 | 0.176491
0.68 | 0.068801 | 0.177935
0.685 | 0.069367 | 0.179332
0.69 | 0.069933 | 0.180776
0.695 | 0.070500 | 0.182223
0.7 | 0.071068 | 0.183655
0.705 | 0.071636 | 0.185097
0.71 | 0.072204 | 0.186566
0.715 | 0.072773 | 0.188031
0.72 | 0.073342 | 0.189474
0.725 | 0.073912 | 0.190927
0.73 | 0.074482 | 0.192387
0.735 | 0.075053 | 0.193853
0.74 | 0.075624 | 0.195340
0.745 | 0.076196 | 0.196875
0.75 | 0.076768 | 0.198311
0.755 | 0.077340 | 0.199836
0.76 | 0.077913 | 0.201264
0.765 | 0.078486 | 0.202826
0.77 | 0.079060 | 0.204352
0.775 | 0.079634 | 0.205841
0.78 | 0.080209 | 0.207305
0.785 | 0.080784 | 0.208777
0.79 | 0.081359 | 0.210227
0.795 | 0.081935 | 0.211682
0.8 | 0.082511 | 0.213107
0.805 | 0.083088 | 0.214690
0.81 | 0.083664 | 0.216142
0.815 | 0.084242 | 0.217673
0.82 | 0.084819 | 0.219141
0.825 | 0.085397 | 0.220647
0.83 | 0.085976 | 0.222105
0.835 | 0.086555 | 0.223606
0.84 | 0.087134 | 0.225098
0.845 | 0.087713 | 0.226622
0.85 | 0.088293 | 0.228080
0.855 | 0.088874 | 0.229562
0.86 | 0.089454 | 0.231028
0.865 | 0.090035 | 0.232500
0.87 | 0.090616 | 0.233996
0.875 | 0.091198 | 0.235503
0.88 | 0.091780 | 0.237054
0.885 | 0.092362 | 0.238547
0.89 | 0.092945 | 0.240025
0.895 | 0.093527 | 0.241601
0.9 | 0.094111 | 0.243159
0.905 | 0.094694 | 0.244570
0.91 | 0.095278 | 0.246027
0.915 | 0.095862 | 0.247483
0.92 | 0.096446 | 0.248943
0.925 | 0.097031 | 0.250432
0.93 | 0.097616 | 0.252007
0.935 | 0.098201 | 0.253544
0.94 | 0.098787 | 0.255158
0.945 | 0.099373 | 0.256670
0.95 | 0.099959 | 0.258152
0.955 | 0.100545 | 0.259617
0.96 | 0.101132 | 0.261115
0.965 | 0.101719 | 0.262588
0.97 | 0.102306 | 0.264141
0.975 | 0.102894 | 0.265622
0.98 | 0.103481 | 0.267241
0.985 | 0.104069 | 0.268790
0.99 | 0.104658 | 0.270316
0.995 | 0.105246 | 0.271877
1 | 0.105835 | 0.273385
1.005 | 0.106424 | 0.274812
1.01 | 0.107013 | 0.276329
1.015 | 0.107602 | 0.277814
1.02 | 0.108192 | 0.279298
1.025 | 0.108782 | 0.280872
1.03 | 0.109372 | 0.282380
1.035 | 0.109962 | 0.283922
1.04 | 0.110553 | 0.285386
1.045 | 0.111144 | 0.286909
1.05 | 0.111735 | 0.288402
1.055 | 0.112326 | 0.289922
1.06 | 0.112917 | 0.291435
1.065 | 0.113509 | 0.292879
1.07 | 0.114100 | 0.294474
1.075 | 0.114692 | 0.295999
1.08 | 0.115284 | 0.297518
1.085 | 0.115877 | 0.298972
1.09 | 0.116469 | 0.300550
1.095 | 0.117062 | 0.302065
1.1 | 0.117655 | 0.303613
1.105 | 0.118248 | 0.305145
1.11 | 0.118841 | 0.306649
1.115 | 0.119434 | 0.308151
1.12 | 0.120028 | 0.309687
1.125 | 0.120621 | 0.311154
1.13 | 0.121215 | 0.312654
1.135 | 0.121809 | 0.314159
1.14 | 0.122403 | 0.315747
1.145 | 0.122997 | 0.317343
1.15 | 0.123592 | 0.318798
1.155 | 0.124186 | 0.320339
1.16 | 0.124781 | 0.321898
1.165 | 0.125376 | 0.323403
1.17 | 0.125970 | 0.324866
1.175 | 0.126566 | 0.326341
1.18 | 0.127161 | 0.327838
1.185 | 0.127756 | 0.329436
1.19 | 0.128351 | 0.330948
1.195 | 0.128947 | 0.332439
1.2 | 0.129542 | 0.334006
1.205 | 0.130138 | 0.335611
1.21 | 0.130734 | 0.337149
1.215 | 0.131330 | 0.338684
1.22 | 0.131926 | 0.340247
1.225 | 0.132522 | 0.341707
1.23 | 0.133118 | 0.343233
1.235 | 0.133715 | 0.344674
1.24 | 0.134311 | 0.346155
1.245 | 0.134908 | 0.347584
1.25 | 0.135504 | 0.349037
1.255 | 0.136101 | 0.350615
1.26 | 0.136697 | 0.352113
1.265 | 0.137294 | 0.353670
1.27 | 0.137891 | 0.355131
1.275 | 0.138488 | 0.356666
1.28 | 0.139085 | 0.358203
1.285 | 0.139682 | 0.359700
1.29 | 0.140279 | 0.361165
1.295 | 0.140876 | 0.362757
1.3 | 0.141473 | 0.364325
1.305 | 0.142071 | 0.365872
1.31 | 0.142668 | 0.367334
1.315 | 0.143265 | 0.368723
1.32 | 0.143863 | 0.370181
1.325 | 0.144460 | 0.371721
1.33 | 0.145058 | 0.373261
1.335 | 0.145655 | 0.374706
1.34 | 0.146253 | 0.376133
1.345 | 0.146850 | 0.377604
1.35 | 0.147448 | 0.379100
1.355 | 0.148045 | 0.380737
1.36 | 0.148643 | 0.382290
1.365 | 0.149240 | 0.383777
1.37 | 0.149838 | 0.385274
1.375 | 0.150436 | 0.386885
1.38 | 0.151033 | 0.388377
1.385 | 0.151631 | 0.389824
1.39 | 0.152229 | 0.391374
1.395 | 0.152826 | 0.392832
1.4 | 0.153424 | 0.394267
1.405 | 0.154022 | 0.395799
1.41 | 0.154619 | 0.397244
1.415 | 0.155217 | 0.398760
1.42 | 0.155814 | 0.400222
1.425 | 0.156412 | 0.401658
1.43 | 0.157010 | 0.403158
1.435 | 0.157607 | 0.404671
1.44 | 0.158205 | 0.406221
1.445 | 0.158802 | 0.407698
1.45 | 0.159400 | 0.409225
1.455 | 0.159997 | 0.410682
1.46 | 0.160594 | 0.412195
1.465 | 0.161192 | 0.413700
1.47 | 0.161789 | 0.415198
1.475 | 0.162386 | 0.416634
1.48 | 0.162984 | 0.418144
1.485 | 0.163581 | 0.419655
1.49 | 0.164178 | 0.421166
1.495 | 0.164775 | 0.422655
1.5 | 0.165372 | 0.424148

Extra risk at dose = 0 is zero by definition.

##### Fatal IHD lifetime extra risks

Two studies in the IHD database performed analyses of fatal IHD cases rather than analysis of incident only IHD or incident plus fatal cases of IHD: (Moon et al., 2013; Chen et al., 2011) (see Table C-50 for fatal-only studies). Thus, while the main assessment notes that, for the purpose of toxicity value derivations, EPA considers the minimum number of studies for a dose-response meta-analysis to be three, it is possible to perform a Bayesian dose-response meta-analysis of just two studies to generate lifetime extra risks for fatal IHD (see Table C-60). While statistically valid, the lifetime extra risks generated via this analysis are more uncertain compared to lifetime extra risks for other endpoints (that are based on meta-analyses of ≥ three studies. Further, fatal IHD is an important endpoint for monetization in cost-benefits analysis and lifetime extra risks for fatal IHD are informative when compared to lifetime extra risks for incident plus fatal IHD.

Calculation of lifetime extra risks based on individual fatal IHD studies was not pursued. It could be argued that calculating lifetime extra risks from modeling based on the U.S. study (Moon et al., 2013) is reasonable. However, the use of a single study investigating the effect of iAs exposure on IHD mortality in a potentially sensitive population and then extrapolating those effects to the general U.S. population using age-stratified general U.S. data could be more uncertain than using the results of a two-study dose-response meta-analysis. One approach would be to source a lifetime probability of disease in the sensitive subpopulation being modeled, but then the lifetime extra risks estimated may not be generalizable to the U.S. population. Given these concerns, EPA determined that reporting lifetime extra risks from the two-study dose-response meta-analysis was the approach associated with the least uncertainty.

The lifetime extra risks reported in Table C-60 and Figure C-30 are based on a lifetime probability of approximately 7.7% for IHD mortality (calculated from data presented in Table C-61).

Table C-60 Lifetime extra risks for fatal IHD

Extra lifetime risk estimates (per 10,000)^a^ | Average inorganic arsenic dose (µg/kg-day)^b^
Extra lifetime risk estimates (per 10,000)^a^ | 0 | 0.13^c^ | 0.2 | 0.3 | 0.4 | 0.5 | 0.6 | 0.7 | 0.8 | 0.9 | 1.0
5th % | 0 | 0.18 | 0.30 | 0.49 | 0.69 | 0.89 | 1.10 | 1.33 | 1.55 | 1.79 | 2.04
Mean | 0 | 27.39 | 45.63 | 74.99 | 108.23 | 145.55 | 187.22 | 233.52 | 284.69 | 340.88 | 402.12
95th % | 0 | 94.52 | 156.22 | 258.38 | 375.33 | 508.07 | 660.11 | 832.67 | 1,027.67 | 1,243.05 | 1,483.36

a Extra lifetime risks are presented as mean risk with 5%–95% probabilities based on mean, 5% and 95% estimates of dose-response slopes.

b Doses used in EPA modeling. U.S. daily background dose is estimated at 0.0365 µg/kg–day, 0.02 µg/kg–day from diet, 0.0165 µg/kg–day from water and 0 µg/kg–day from air (see Section 4.3.4).

c Daily intake associated with the current MCL of 10 μg/L drinking water assuming 0.011 L/kg-day water consumption rate and 0.02 0.02 μg/kg-day from diet.

Figure C-30 U.S. fatal IHD lifetime extra risks versus µg/kg-day doses for doses up to 1.0 µg/kg-day

The polynomial trendline formulas given in Figure C-30 are provided for convenience in approximating a lifetime extra risk at doses and exposures other than those presented in Table C-60.

Table C-61 Lifetable rates for all-cause mortality and IHD mortality

Age range | All-cause mortality rates (per 100,000)^a^ | IHD mortality rates (per 100,000)^a^
0–1 | 594.7 | 0
1–4 | 25.5 | 0
5–9 | 11.8 | 0
10–14 | 14.1 | 0
15–19 | 44.8 | 0.3
20–24 | 83.4 | 0.3
25–29 | 97.6 | 2.4
30–34 | 114.8 | 2.4
35–39 | 141.9 | 12.3
40–44 | 200.3 | 12.3
45–49 | 315.1 | 48.5
50–54 | 491.6 | 48.5
55–59 | 721.8 | 121.1
60–64 | 1,021.7 | 121.1
65–69 | 1,468.4 | 258.1
70–74 | 2,261.7 | 258.1
75–79 | 3,611.9 | 683.5
80–84 | 6,027.4 | 683.5

a National Vital Statistics Report, Volume 64, Number 2, 2/16/2016. Final data for 2013: https://www.cdc.gov/nchs/data/nvsr/nvsr64/nvsr64_02.pdf.

### C.1.3 Calculation of Benchmark Doses for IHD and Diabetes

The approach used for deriving benchmark doses (BMDs) and the 95th lower bounds on the benchmark dose (BMDLs) for IHD and diabetes is discussed in this section. Briefly, after applying the dose-response meta-analysis approach described in Section C.1.1, which yields a posterior distribution for values of β and power, q, BMDs and BMDLs were estimated for IHD and diabetes by following the steps outlined here.

First, as discussed elsewhere, note that the lifetime probability of the endpoint in question, P_b_, is associated with a background level of exposure, d_b_, both of which are known (estimated from the literature). Consequently, for any given value of β and q we have:

P_b_ = (1)/(1 + exp ( − α − β ⋅ d_b_^q^ )) (C-53)

from which we can solve for α:

α = − ln ( (1)/(P_b_) − 1 ) − β ⋅ d_b_^q^ (C-54)

Given α, the lifetime probability of the endpoint at 0 dose is equal to:

P_0_ = (1)/(1 + exp ( − α )) (C-55)

which is associated with an odds of getting the endpoint of

(P_0_)/(1 − P_0_) (C-56)

Now, a BMD associated with an extra risk equal to a specified benchmark response (BMR; e.g., 0.01, 0.05, or 0.10), is defined as the solution to:

B M R = (P_B M D_ − P_0_)/(1 − P_0_) (C-57)

So with a known P_0_, from above, one can solve for P_BMD_:

P_B M D_ = B M R ( 1 − P_0_ ) + P_0_ (C-58)

which also has an associated odds of getting the endpoint of

(P_B M D_)/(1 − P_B M D_) (C-59)

Finally, as is well known for the Logistic equation, the odds ratio, in this case for the BMD compared to 0 dose, which is simply the odds at BMD divided by the odds at 0, is equal to:

O R = exp ( β ⋅ B M D^q^ ) (C-60)

And this can be solved for BMD:

B M D = root((ln ( O R ))/(β), q) (C-61)

BMDs were obtained for the endpoints of interest by solving the equations above for each sampled pair of βmean and q from the posterior draw and taking the median. BMDLs were set equal to the 5th percentile of those calculated values.

The process to select the benchmark response for the IHD endpoint involved the consideration of both fatal and incident cases of IHD in the five studies comprising the dose-response meta-analysis. Two of the studies, Wade et al. (2015) and Wu et al. (2010), did not include fatal cases of disease and thus a BMR = 5% extra risk is reasonable as incident cases of IHD are not considered frank effects. The remaining three studies, Moon et al. (2013), Chen et al. (2013), and James et al. (2015) did include incident and fatal cases of disease. While fatal cases of IHD would be considered frank effects and thus support a BMR = 1% extra risk, applying that BMR to the entire study would result in treating incident cases as frank effects, inconsistent with the determination of the appropriate BMR level for incident-only studies. The Moon et al. (2013) study reports the number of incident and fatal cases and fatal-only cases, enabling the ability to investigate the proportion of incident cases in the study. For example, there are 202, 206, 197, and 241 cases of incident and fatal cases of IHD in the individual exposure groups used in Moon et al. (2013), while there are only 68, 67, 87, and 119 cases of fatal IHD in those same exposure groups. Therefore, the proportion of incident cases of IHD across the exposure groups is approximately 60%, compared to 40% for fatal cases. While Chen et al. (2013) and James et al. (2015) do not separately report incident plus fatal cases and fatal-only cases, it is reasonably assumed that the same pattern of more incident cases than fatal cases across exposure groups holds for these studies as well. Thus, it is possible to calculate a weighted (by sample size) BMR across all studies that accounts for the application of a BMR = 1% extra risk for fatal cases and a BMR = 5% extra risk for incident cases. Doing so results in a BMR = 3.86%~3.9% extra risk.

The estimate of 60% incident (non-fatal) cases to 40% fatal cases is the only empirical data specific to iAs exposure that is currently available on this proportion, and thus this proportion is inferred for the studies by Chen et al. (2013) and James et al. (2015) in the dose-response modeling. However, this is likely a conservative assumption given the expected increased susceptibility of the study population evaluated by Moon et al. (2013). Moreover, while the general trend is consistent with U.S. statistics, estimates of the general U.S. population show the proportion to be more skewed toward non-fatal cases, including estimate from around the timeframe relevant to these two studies (1995–2002) of around 80% incident cases : 20% fatal cases (https://jamanetwork.com/journals/jamanetworkopen/fullarticle/2728009); thus, the impact of applying this alternative 80:20 proportion on the estimation of the weighted BMR and BMD modeling is included for comparison. However, as the proportions vary depending on the study population (e.g., sex; age; ethnicity), methods and definitions used, and timing (generally, with fewer fatal cases over time, attributable in part to improvements in medical procedures and medication), the actual study-specific proportions remain an uncertainty. Using the 80:20 proportion split to estimate the weighted BMR results in a BMR of 4.4% extra risk.

Additionally, although the minimum number of studies to support a dose-response meta-analysis is reported to be three in the main assessment, two supplemental dose-response meta-analysis consisting of only two studies were conducted to generate BMDL values for fatal-only (see Table C-50 for fatal-only studies) and incident-only studies for comparison purposes to the BMDL for incident and fatal IHD cases. Given these BMDL values for fatal-only and incident-only studies are based only on two studies each, the resulting values are more uncertain than the main analysis (i.e., five-study dose-response meta-analysis for IHD incident and fatal cases). Thus, the fatal-only and incident-only BMDLs should only be considered in the context of this comparison. A BMR = 1% was used for the fatal-only IHD analysis and a BMR = 5% was used for the incidence-only IHD analysis (see Table C-62).

Table C-62 Benchmark dose derivations for various IHD dose-response meta-analyses

Analysis | Studies | BMR | BMD (µg/kg-day) | BMDL (µg/kg-day)
Fatal-only | (Chen et al., 2011); (Moon et al., 2013); | 1% extra risk | 0.6229 | 0.1399
Incidence-only | (Wade et al., 2015); (Wu et al., 2010) | 5% extra risk | 0.8466 | 0.2271
Incidence + fatal | (Chen et al., 2013); (Moon et al., 2013); (James et al., 2015); (Wade et al., 2015). (Wu et al., 2010) | 3.9% extra risk ^a^ | 0.4886 | 0.1707
Incidence + fatal | (Chen et al., 2013); (Moon et al., 2013); (James et al., 2015); (Wade et al., 2015). (Wu et al., 2010) | 4.4% extra risk | 0.5437 | 0.1910
Incidence + fatal | (Chen et al., 2013); (Moon et al., 2013); (James et al., 2015); (Wade et al., 2015). (Wu et al., 2010) | 5% extra risk | 0.6089 | 0.2150

a Analysis reported in the main assessment.

As can be seen, the BMDL_01_ for the fatal-only analysis was the lowest (0.1399 µg/kg-d), but it was also the BMDL associated with the widest BMD-BMDL width (4.4), which is to be expected given it is based on a dose-response meta-analysis of only two studies. The BMD derivation reported in the main assessment, based on IHD (incident and fatal cases) using a BMR = 3.9% extra risk, resulted in a slightly higher BMDL (0.1707 µg/kg-d). However, there is less uncertainty with this analysis given it is based on more studies (five vs. two), evident in that the width of the BMD-BMDL interval is 2.9 (compared to 4.4 for the fatal-only analysis).

## C.2 DOSE-RESPONSE ANALYSIS FOR BIRTH WEIGHT EFFECTS

### C.2.1 Meta-Analysis Methods for Decreased Birthweight

Following literature searches up to August 2022, EPA identified 87 fetal, newborn, and infant health outcome studies that were of high or medium confidence. A standardized study-selection process was applied in order to identify studies most appropriate for dose-response and point-of-departure derivation. The criteria considered particularly important for fetal, newborn, and infant health outcomes included study design (i.e., case-control or cohort); exposure metric (i.e., use of exposure metric that is or can be converted to an oral ingestion rate such as drinking water concentrations or maternal urinary concentrations); whether smoking was adequately addressed in the study design and/or analysis, risk metrics reported (i.e., beta coefficients); and prioritized endpoint (birth weight).

Ultimately, seven studies were considered for the dose-response of birth weight outcomes: (Rahman et al., 2009; Liu et al., 2018; Liao et al., 2018; Laine et al., 2015; Kile et al., 2016; Goodrich et al., 2019; Gilbert-Diamond et al., 2016). Two data sets were from U.S. populations, two were from Bangladesh, and one each were from China, Taiwan, and Mexico. See Table C-63 below for study details.

Table C-63 Data sets selected for birthweight dose-response analyses

Study | Location | Exposure/dose metric | Exposure range (median, range) | Beta coefficient | Sample timing | Description
Gilbert-Diamond et al. (2016) | New Hampshire, United States | Maternal total As urinary concentration (sum of iAs, MMA, DMA) | 3.4 µg/L (IQR: 1.7–6.0 µg/L) | −1.3 g/ln(µg/L) (−35.8, 33.2); Re-expressed to normal scale:; −0.35 g/µg/L (−9.64, 8.94) | 2nd–3rd trimester | 706 mother-child dyads from New Hampshire Birth Cohort, spot urine samples collected at approximately 24–28 wk of gestation, samples adjusted for urinary dilution via creatinine (sub-analysis showed no difference between adjusted and unadjusted results)
Goodrich et al. (2019) | Michigan, United States | Maternal total As urinary concentration (not reported what species summed to generate estimate) | 3.8 µg/L (IQR: 1.69–8.58 µg/L) | 9.03 g/ln(µg/L) (−92.34, 110.39); Re-expressed to normal scale:; 2.06 g/µg/L (−21.04, 25.16) | 1st trimester | 56 mother-child dyads from the Michigan Mother Child Pair study, spot urine samples taken during 1st trimester prenatal appointment, samples adjusted for urinary dilution via specific gravity
Kile et al. (2016) | Bangladesh | Drinking water concentration | 2.3 µg/L (IQR: 0.90–36.0 µg/L) | −17.4 g/ln(µg/L) (−22.8, −12.0); Re-expressed to normal scale:; −3.91 g/µg/L (−5.13, −2.70) | Drinking water sampled at time of enrollment | Prospective birth cohort in Bangladesh, 1,140 mother-child dyads
Laine et al. (2015) | Mexico | Maternal total As urinary concentration (sum of iAs, MMA, DMA) | 23.3 µg/L (range: 4.3–319.7 | −0.58 g/µg/L (−2.1, 0.93) | Post-natal (within four wk of birth) | 200 mother-child dyads recruited into Biomarkers of Exposure to Arsenic prospective pregnancy cohort within 24 hr of birth, urine samples collected at hospital prior to birth, urine samples adjusted for urinary dilution via specific gravity
Liao et al. (2018) | Taipei, Taiwan | Maternal total As urinary concentration (reported as total urinary As but not reported what species summed to generate estimate) | 41.1 µg/L (IQR: 21.8–74.5 µg/L) (3rd trimester) | −14.5 g/log_10_(µg/L) (−161.22, 132.2); Re-expressed to normal scale:; −0.14 g/µg/L (−1.57, 1.29) | 1st, 2nd, 3rd trimester | 130 mother-child dyads identified from Cathay General Hospital, Taiwan, spot urine samples taken during each trimester (3rd trimester results used in meta-analysis), urine samples not adjusted for urinary dilution
Rahman et al. (2009) | Bangladesh | Maternal total As urinary concentration (sum of iAs, MMA, DMA) | 95 µg/L (10th–90th percentile: 26–444 µg/L), analysis restricted to women with <100 µg/L | −1.48 g/µg/L (SE: 0.56) | Average of 1st and 3rd trimester measurements | 805 mother-child dyads (51% of women from full cohort, N = 1,578, that had urinary As concentrations <100 µg/L, spot urine samples taken during 1st and 3rd trimesters and averaged, urine samples adjusted for urinary dilution via specific gravity
Liu et al. (2018) | Wuhan, China | Maternal total as urinary concentration (sum of inorganic and organic As species) | 21.08 µg/L (IQR; 15.22–30.52 µg/L) (3rd trimester) | −24.27g/log_2_(µg/L) (−46.99, −1.55); Re-expressed to normal scale:; −1.62 g/µg/L (−3.13, °0.1) | 1st, 2nd, 3rd trimester | 1390 mother-child dyads in Wuhan China, spot urine samples taken during each trimester (3rd trimester results used in meta-analysis), urine samples adjusted for urinary dilution via specific gravity

Of the studies that reported beta coefficients, only Kile et al. (2016) reported the effect in units of drinking water arsenic (μg/L); all other studies (Rahman et al., 2009; Liu et al., 2018; Liao et al., 2018; Laine et al., 2015; Goodrich et al., 2019; Gilbert-Diamond et al., 2016) reported effect estimates based on maternal urinary total As concentration. As stated in the assessment (see Section 4.4), given the potential mediating role of gestational age on the association between arsenic and birth weight (Wilcox et al., 2011; Kile et al., 2016), EPA’s primary meta-analysis to derive a POD for birth weight was restricted to maternal urinary studies that did not adjust for this variable (Rahman et al., 2009; Liu et al., 2018; Laine et al., 2015)

For the studies that reported beta coefficients using a log-transformation of the arsenic concentration, the log-transformed betas (i.e., per log_x_(µg/L)) were re-expressed to the natural scale (i.e., per µg/L) to standardize units and reduce the between-study heterogeneity. The approach described in Dzierlenga et al. (2020) was used and is summarized as follows, using Kile et al. as an example. Kile et al. (2016) reported a β coefficient of −17.4 g (95% CI: −22.80, −12.0) per ln(µg/L) increase for the association between birth weight and iAs concentrations in drinking water in a Bangladesh cohort, based on their multiple linear regression analysis. Given the reported study-specific median (2.3 µg/L) and interquartile range (IQR) (0.9–36 µg/L) of the exposure from Kile et al. (2016), the distribution of exposure was estimated by assuming the exposure follows a log-normal distribution with mean and standard deviation:

μ = ln ( q_50_ ) = ln ( 2.3 ) = 0.83 (C-62)

σ = ln ( q_75_ / q_25_ ) / 1.349 = ln ( 0.9 / 36 ) / 1.349 = 2.73 (C-63)

Then, the 25th through 75th percentiles at 10 percentile intervals of the exposure distribution and corresponding responses of reported β coefficient were estimated. The re-expressed β coefficient is determined by minimizing the sum of squared differences between the curves generated by the re-expressed β and the reported β. Doing so results in a re-expressed β coefficient of −3.91 g (95% CI: −5.13, −2.70) per µg/L. This process was used for all studies reporting log_x_-transformed beta coefficients and the re-scaled beta coefficients on the natural scale are reported in Table C-63.

For the meta-analysis of three studies reporting beta coefficients per maternal urinary tAs concentrations and not controlling for gestational age, the R-based meta-analysis package metafor (version 4.6.0) with default options was used. The meta-analysis was carried out using a random-effects model, following the assumption that each study produced an estimate of a study-specific true effect that varies across studies (Borenstein et al., 2009). Inverse-variance weighting was employed to minimize the influence of both sampling variance and between-study variance on the pooled effect estimate. The amount of variation due to study heterogeneity was captured by two metrics: the I^2^ statistic and Cochran’s Q Test. The I^2^ statistic represents the percentage of variation in the pooled estimate due to between-study heterogeneity. Considering the range of values shown in Cochran’s I^2^ guidelines (Higgins et al., 2022), EPA considered I^2^ statistics <40% to represent “low” potential heterogeneity, with values from 40% to 69% being “moderate” and values ≥70% representing “high” heterogeneity. Cochran’s Q test evaluates whether the dispersion of study-specific estimates about the pooled effect estimate is statistically significant via a p-value (p_Q_), based on significance level (α) of 0.05. Both metrics may suffer from low statistical power when few studies are available, potentially complicating interpretation of the examinations of heterogeneity. Thus, consideration of both measures in conjunction is recommended to identify situations in which significant heterogeneity may be present (Huedo-Medina et al., 2006).

The overall pooled effect estimate from these three studies based on the random-effects model was −1.28 g (95% CI: −2.05, −0.52; SE = 0.39) of birth weight per (µg/L) increase in maternal urinary tAs concentration (see Figure C-31). The I^2^ test for heterogeneity showed that between-study variability is well within the “low” level, and the Cochran’s Q test showed strong non-significance regarding evidence for heterogeneity (I^2^ = 0.0%, p_Q_ = 0.56).

Figure C-31 Forest plot of three studies included for the primary meta-analysis on maternal total iAs concentrations and changes in birth weight

A leave-one-out analysis was not attempted for the birth weight meta-analysis given that only three studies were included in the main analysis. However, from the forest plot above, it can be seen that the Rahman et al. (2009) study most strongly influenced the pooled analysis, evident by the width of the study-specific confidence intervals and the thickness of the forest plot data point. Removal of this study would reduce the overall pooled effect (should a meta-analysis of only two studies be conducted).

Publication bias was also investigated via Egger’s regression and visual inspection of a funnel plot (see Figure C-32). The Egger’s regression test did not detect a statistically significant relationship between the observed effect sizes and their standard errors (p = 0.63), indicating no evidence of funnel plot asymmetry due to publication bias. The funnel plot is displayed below.

Figure C-32 Funnel plot of three studies included for the primary meta-analysis on maternal total iAs concentrations and changes in birth weight

Finally, a sensitivity analysis was conducted in which all six birth weight studies were included in the meta-analysis, irrespective of if gestational age was controlled for in the study-specific analyses. This meta-analysis resulted in a pooled beta of −1.02 g per μg/L (95% CI: −1.71, −0.34). The results of this sensitivity meta-analysis were attenuated slightly from the main analysis, mainly due to the fact that all of the studies added to the meta-analysis were null (i.e., confidence intervals including zero). Further, these attenuated results with the inclusion of studies controlling for gestational age are unsurprising, given the evidence that gestational age plays a strong mediating role in the impact of arsenic on birth weight. As with the main analysis, measures of heterogeneity indicated low heterogeneity across included studies (I^2^ = 2.0% and Cochrane’s Q p-value = 0.68).

In order to calculate a point of departure in units of daily iAs intake (µg/kg-day), the BMD and BMDL derived in units of µg/L maternal urinary tAs from the primary meta-analysis (BMD = 72.19 µg/L, BMDL = 48.08 µg/L; see Section 4.4.1) was converted using the relationship between iAs exposure in drinking water and maternal urinary tAs concentration described in the Gilbert-Diamond et al. (2016) study (see below).

Gilbert-Diamond et al. (2016) investigated the association of drinking water ingestion and rice consumption on maternal urinary tAs concentration and derived the following regression equation:

U r i n a r y t A s ( ln ( (μ g)/(L) ) ) = 0.028 ( ln ( (μ g)/(L) ) p e r (μ g)/(d) ) × d r i n k i n g w a t e r ( (μ g)/(d) ) + 0.009 ( ln ( (μ g)/(L) ) p e r (g)/(d) ) × r i c e ( (g)/(d) ) + 0.012 ( ln ( (μ g)/(L) ) p e r y e a r ) × a g e ( y e a r ) + 0.011 ( ln ( (μ g)/(L) ) p e r (m g)/(d L) ) × c r e a t i n i n e ( (m g)/(d L) ) − 0.165 ( ln ( (μ g)/(L) ) ) (C-64)

Rearranging this equation to solve for drinking water exposure, results in:

d r i n k i n g w a t e r ( (μ g)/(d) ) = (u r i n a r y t A s ( ln ( (μ g)/(L) ) ) − 0.009 ( ln ( (μ g)/(L) ) p e r (g)/(d) ) × r i c e ( (g)/(d) ) − 0.012 ( ln ( (μ g)/(L) ) p e r y e a r ) × a g e ( y e a r ) − 0.11 ( ln ( (μ g)/(L) ) p e r (m g)/(d L) ) × c r e a t i n i n e ( (m g)/(d L) ) + 0.165 ( ln ( (μ g)/(L) ) ))/(0.028 ( ln ( (μ g)/(L) ) )) (C-65)

Thus, the BMD for birth weight, 72.19 μg/L maternal arsenic, as derived in the primary meta-analysis in Section 4.4.1, can be converted to drinking water exposure in units of µg/day using values for the equation inputs: average rice consumption in pregnant women of 16.1 g/day (U.S. Exposure Factors Handbook, Table 12-37), average creatinine concentrations during pregnancy of 61 mg/dL (Wiles, et al. 2019, doi: 10/1016/j.ekir.2018.10.015), and average age at first pregnancy of 24.1 years (NHSR, No 179, Jan 10, 2023). The BMD would be calculated as:

d r i n k i n g w a t e r ( (μ g)/(d) ) = (( ln ( 92.4 (μ g)/(L) ) ) − 0.009 ( ln ( (μ g)/(L) ) p e r (g)/(d) ) × 16.1 ( (g)/(d) ) − 0.012 ( ln ( (μ g)/(L) ) p e r y e a r ) × 24.1 ( y e a r ) − 0.011 ( ln ( (μ g)/(L) ) p e r (m g)/(d L) ) × 61 ( (m g)/(d L) ) + 0.165 ( ln ( (μ g)/(L) ) ))/(0.028 ( ln ( (μ g)/(L) ) )) d r i n k i n g w a t e r ( (μ g)/(d) ) = 119.3 (μ g)/(d) (C-66)

Dividing that value by a standard body weight of 75 kg for pregnant women (U.S. Exposure Factors Handbook, Table 8-29) would result in a BMD of 1.59 µg/kg-day. Calculating the BMDL in units of daily intake in the same manner would result in a value of 1.40 µg/kg-day.

## C.3 DOSE-RESPONSE ANALYSIS FOR DEVELOPMENTAL NEUROCOGNITIVE EFFECTS

### C.3.1 Meta-Analysis Methods for Neurodevelopmental Endpoints

Following literature searches up to August 2024, EPA identified 63 developmental neurocognitive studies that were of high or medium confidence. A standardized study-selection process was applied in order to identify studies most appropriate for dose-response and point-of-departure derivation. The criteria considered particularly important for developmental neurocognitive studies included study design (i.e., case-control, cohort, or cross-sectional); exposure metric (i.e., use of an exposure metric that is or can be converted to an oral ingestion rate such as drinking water concentrations or maternal urinary concentrations); whether smoking was adequately addressed in the study design and/or analysis; risk metrics reported (i.e., beta coefficients); and prioritized endpoint (cognitive effects). Note that while smoking was considered a critical confounder with respect to identification of studies appropriate for dose-response, other important confounders such as sex, age, and socioeconomic status (e.g., education or income) were also considered as part of the risk of bias analysis (see HAWC:). The full list of confounders controlled for in the individual studies are listed in Table C-64 below.

Ultimately, three studies were considered for the dose-response of developmental neurocognitive effects: (Soler-Blasco et al., 2022; Signes-Pastor et al., 2022; Chen et al., 2023). One dataset each were from the United States, Spain, and China. See Table C-64 below for study details.

Table C-64 Data sets selected for neurocognitive effects dose-response analyses

Study | Location | Exposure/dose metric | Exposure range (median, range) | Beta coefficient | Sample timing | Description
Soler-Blasco et al. (2022) | Gipuzkoa and Valencia regions of Spain (INMA cohort) | Maternal total As urinary concentration (sum of iAs, MMA, DMA) | 6.26 µg/L (IQR: 3.7–10.73 µg/L) | Age 5 = −0.49 g/log_2_(µg/L) (−1.58, 0.59) | 1st trimester | 741 mother-child dyads from INMA (Child and Environment) Project cohort, spot urine samples collected at approximately 13 wk of gestation, urinary dilution accounted for via controlling for creatinine in statistical models. Neurocognitive ability assessed by the McCarthy Scales of Children’s Ability (MSCA) adapted for the Spanish population (mean = 100, sd = 15) at age five (mean [sd] age = 5.2 [0.7]); Confounders included in analysis: area of study, maternal urinary creatinine, maternal education level, paternal education level, parity, season of sample collection, child’s sex, nursery attendance, maternal verbal intelligence, rice consumption, seafood consumption. Smoking and parental social class initially considered as confounders but were found to not be statistically significantly associated with neuropsychological assessment.
Signes-Pastor et al. (2022) | Cincinnati, Ohio United States | Maternal total As urinary concentration (sum of iAs, MMA, DMA) | 3.63 µg/L (IQR: 2.4–5.86 µg/L) | Age 2, all women = −1.1 g/log_2_(µg/L) (−3.5, 1.2); Age 2, low arsenobetaine (AsB) women = −0.5 g/log_2_(µg/L) (−3.7, 2.6); Age 5, all women = −2.5 g/log_2_(µg/L) (−5.1, 0.0); Age 5, low arsenobetaine (AsB) women = −4.1 g/log_2_(µg/L) (−7.4, 0.7) | 2nd and 3rd trimester | 260 mother-child dyads from the HOME Study, spot urine samples taken during 2nd and 3rd trimesters prenatal appointment, urinary dilution accounted for via controlling for creatinine in statistical models. Seafood consumption investigated via sub-analysis of women with low AsB levels (n = 167), this analysis was reported as “underpowered” by study authors and results for main analysis used in meta-analysis, Neurocognitive ability assessed by the Bayley Scales of Infant Development (BSID) at age two and Wechsler Preschool and Primary Scale of Intelligence (WPPSI) at age five; both tests reported to have mean of 100 and standard deviation of 15.; Confounders included in analysis: household income, maternal race, maternal age at delivery, maternal intelligence quotient measured by Wechsler Abbreviated Scale of Intelligence, maternal pre-pregnancy BMI, pregnancy cotinine levels, creatinine, HOME score, child’s sex.
Chen et al. (2023) | Wuhan, China | Maternal total As urinary concentration (sum of iAs, MMA, DMA) | 13.95 µg/L (IQR: 11.24–17.43 µg/L) | Age 2 = −2.57 g/log_2_(µg/L) (−5.22, 0.07) | 1st, 2nd, and 3rd trimesters | 1,006 mother-child dyads recruited from the Wuhan Medical and Healthcare Center for Woman and Children, Wuhan, China; spot urine samples taken during 1st, 2nd, and 3rd trimesters, urinary dilution accounted for via specific gravity. AsB not specifically accounted for, but study authors note that excluding AsB from summed As urinary biomarker helps “… minimize exposure misclassification and to assess the health effects of arsenic more accurately.” Neurocognitive ability assessed by the Bayley Scales of Infant Development (BSID) (mean = 100, sd = 15) at age two. Confounders included in analysis: maternal age, pre-pregnancy BMI, passive smoking, parental education, household annual income, nutrient supplement during pregnancy, child’s sex.

All three of the neurocognitive studies that made it through study selection used log_2_-transformed maternal urinary tAs concentrations as the exposure metric and thus the reported betas are decreased IQ points per log_2_(µg/L). To derive a POD for developmental neurocognitive effects, a meta-analysis of the three maternal urinary studies was conducted using the study reported beta coefficients to reduce between-study heterogeneity and minimize possible bias from re-expression to the normal scale (i.e., re-expression would only be required for the pooled beta coefficient and not for all three studies used in the meta-analysis). All three studies used different neuropsychological assessments to assess cognitive performance at different ages. Soler-Blasco et al. (2022) assessed children at age five using the McCarthy Scale of Children’s Ability (MSCA) and reported children’s general cognitive index (GCI), standardized to a mean of 100 and standard deviation of 15. Chen et al. (2023) assessed children at age two using the Bayley Scales of Infant Development (BSID), which was translated into Chinese and locally standardized. Chen et al. (2023) reported the children’s mental development index (MDI; mean = 100, sd = 15). Lastly, Signes-Pastor et al. (2022) assessed children’s cognitive function at multiple time points using multiple instruments (BSID at age 2 and WPPSI at age 5). To align as close as possible to the ages assessed in the Soler-Blasco et al. (2022) and Chen et al. (2023) studies, the results for cognitive tests administered at age two and five in Signes-Pastor et al. (2022) were considered for the meta-analysis. At age two, Signes-Pastor et al. (2022) reported children’s MDI assessed using the BSID; at age five, children’s full-scale IQ (FSIQ) scores were reported as estimated by the Wechsler Preschool and Primary Scale of Intelligence (WPPSI; mean = 100, sd = 15). The results for “All Women” were used from Signes-Pastor et al. (2022) given concerns expressed by study authors that the alternative analysis of low arsenobetaine women was underpowered. All three outcomes (MDI, GCI, FSIQ) can be considered IQ outcomes (White et al., 2022) and therefore are appropriate and amenable to the application of a meta-analysis given all three outcomes are standardized to the same scale (i.e., mean = 100, sd = 15).

For the meta-analysis of three studies reporting beta coefficients per maternal urinary log_2_(tAs) concentrations, the R-based meta-analysis package metafor (version 4.6.0) was used. The meta-analysis was carried out using a random-effects model, following the assumption that each study produced an estimate of a study-specific true effect that varies across studies (Borenstein et al., 2009). Inverse-variance weighting was employed to minimize the influence of both sampling variance and between-study variance on the pooled effect estimate. The amount of variation due to study heterogeneity was captured by two metrics: the I^2^ statistic and Cochran’s Q Test. The I^2^ statistic represents the percentage of variation in the pooled estimate due to between-study heterogeneity. Considering the range of values shown in Cochran’s I^2^ guidelines (Higgins et al., 2022), EPA considered I^2^ statistics <40% to represent “low” potential heterogeneity, with values from 40% to 69% being “moderate” and values ≥70% representing “high” heterogeneity. Cochran’s Q test evaluates whether the dispersion of study-specific estimates about the pooled effect estimate is statistically significant via a p-value (p_Q_), based on significance level (α) of 0.05. Both metrics may suffer from low statistical power when few studies are available, potentially complicating interpretation of the examinations of heterogeneity. Thus, consideration of both measures in conjunction is recommended to identify situations in which significant heterogeneity may be present (Huedo-Medina et al., 2006).

The overall pooled effect estimate (i.e., meta-analysis beta coefficient) from three studies based on the random-effects model was −1.46 IQ points (95% CI: −3.03, 0.10, SE = 0.8) per log_2_(μg/L) increase in maternal urinary tAs concentration (see Figure C-33). The estimated pooled effect of increasing maternal urinary tAs on decreased IQ score in children did not achieve statistical significance (p = 0.066). The I^2^ test for heterogeneity showed that between-study variability was in the “moderate” level (I^2^ = 46.5%), which is to be reasonably expected for a meta-analysis of only three studies that reported approximately similar results (i.e., all studies reporting inverse associations). The Cochrane’s Q test showed non-significance regarding evidence for heterogeneity (p_0_ = 0.16).

Figure C-33 Forest plot of three studies included for the meta-analysis on maternal total iAs concentrations and changes in IQ scores

A leave-one-out analysis was not attempted for the developmental neurocognitive meta-analysis given that only three studies were included in the main analysis. However, from the forest plot above, it can be seen that the Signes-Pastor et al. (2022) and Chen et al. (2023) studies, although providing less weight than the Soler-Blasco et al. (2022) study (evident in the width of the confidence intervals and thickness of forest plot data points), each strongly influenced the overall pooled estimate. Removal of either of these studies would reduce the overall pooled effect (should a meta-analysis of only two studies be conducted). The Signes-Pastor et al. (2022) study provided the least weight to the overall pooled effect, likely due to the relative imprecision in this study’s beta coefficient given that it only had a sample size of 260 mother-child dyads. Publication bias was also investigated via Egger’s regression and visual inspection of a funnel plot (see Figure C-34). The Egger’s regression test detected a borderline statistically significant relationship between the observed effect sizes and their standard errors (p = 0.06), indicating suggestive evidence of funnel plot asymmetry due to publication bias. This is to be reasonably expected given that only three studies were used in the meta-analysis. The actual level of possible publication bias may be greater than evident in the Egger’s regression results given this test is underpowered when the number of studies included in the meta-analysis is small. The funnel plot is displayed below.

Figure C-34 Funnel plot of three studies included for the meta-analysis on maternal total iAs concentrations and changes in IQ scores

Given that the Signes-Pastor et al. (2022) study measured cognitive function at multiple ages, a sensitivity meta-analysis was conducted using the results of the BSID test administered to study participants at age two. The effect seen at this age in the Signes-Pastor et al. (2022) study (i.e., beta = −1.1 IQ points per log_2_(μg/L); (95% CI: −3.45, 1.25)) was not as strong as that seen at age five (i.e., beta = −2.5 IQ points per log_2_(μg/L); (95% CI: −5.05, 0.05)), and correspondingly, the pooled effect from this alternative meta-analysis was also weaker in magnitude (compared to the main meta-analysis): pooled beta = −0.9 IQ points per log_2_(μg/L); 95% CI: −1.9, 0.1). The Signes-Pastor et al. (2022) study also conducted alternative regression analyses in which effects were estimated only in women that had low urine arsenobetaine (AsB) concentrations. Although the study authors note that “… this sensitivity analysis was likely underpowered given the reduction in sample size…,” comparing the results of meta-analysis using these alternative results from Signes-Pastor et al. (2022) is potentially informative. Restricting the meta-analysis to use the low AsB BSID results from the Signes-Pastor et al. (2022) study resulted in a slightly weaker pooled beta coefficient and wider confidence interval (−0.8 IQ points per log_2_(μg/L); 95% CI: −1.9, 0.3 [low AsB women] vs. −0.9 IQ points per log_2_(μg/L); 95% CI: −1.9, 0.1 [all women]). Conversely, restricting the meta-analysis to use the low AsB WPPSI results from the Signes-Pastor et al. (2022) study resulted in a stronger pooled beta coefficient (−1.94 IQ points per log_2_(μg/L) [low AsB women] vs. −1.46 IQ points per log_2_(μg/L) [all women]). The confidence interval for the pooled low AsB-WPPSI analysis was wider than for the main analysis (95% CI: −4.1, 0.2 [low AsB women] vs. 95% CI: −3.0, 0.1 [all women]). For the low AsB meta-analysis, there was strong statistical evidence of publication bias with an Egger’s regression p-value of 0.019. Given these results, the decision to use the total population analysis from Signes-Pastor in the meta-analysis is supported.

Finally, a sensitivity analysis was conducted in which study-specific log_2_-tranformed betas were re-expressed to the normal scale prior to the meta-analysis (instead of performing the meta-analysis on the log_2_-transformed betas and re-expressing post-hoc). This meta-analysis resulted in pooled beta of −0.2 IQ points per μg/L (95% CI: −0.38, −0.02). The results of this sensitivity meta-analysis are almost identical to those of the main analysis (−0.19 IQ points per μg/L [95% CI: −0.39, 0.01), indicating that when re-expression is conducted (i.e., prior to meta-analysis on study-specific beta coefficients or post-hoc on the pooled beta coefficient) does not have a meaningful impact on BMD and BMDL estimation. Interestingly, the meta-analysis using study-specific beta coefficients re-expressed to the normal scale was associated with less heterogeneity (I^2^ = 0.0% and Cochrane’s Q p-value = 0.21) than the main analysis.

1 A sensitivity analysis using the more complex double Hill and fractional polynomial models that allows for negative response estimates was conducted to verify the reasonableness of this assumption (see Appendix C, Section C.1.1 Sensitivity Analysis of Possible Non-monotonic Dose-Response Relationships).

2 μg/kg is 27 times greater than the estimated U.S. background (median) iAs dose of 0.0365 μg/kg.

3 For computational purposes, 85 years was used to define the upper limit for lifetime risk calculations.

4 Lloyd-Jones et al. (1999) reported lifetime risks of IHD (CHD) at an index age of 40 years for men (48.6%) and women (31.7%) enrolled in the large Framingham Heart Study.

5 Median U.S. dietary consumption of 0.02 µg iAs/kg-day (Xue et al., 2010) plus median U.S. County average inorganic arsenic drinking water concentration (1.5 μg/L) from USGS data (Mendez et al., 2017) multiplied by the average water intake in the U.S. population of 0.011 L/kg-day (U.S. EPA (2019), Table 3-1, “All Ages”).

6 If means or medians were reported for the groups, EPA used either of those values as the representative values for those groups. Moreover, EPA did not consider uncertainty associated with estimating mean values for each group, as discussed later in this subsection.

7 In this document, the term “exposure” represents contact between an agent and a target at an exposure surface; the term “dose” represents the amount of agent that crosses an exposure surface, whether the surface is an absorption barrier or not (e.g., absorption barriers such as the lining of the stomach or lungs versus conceptual surfaces over the nose or open mouth). (Zartarian et al. (2005), official ISEA glossary; J Expo Anal Environ Epidemiol 2005; 15:1–5).

8 “Expected” here refers to what the expected number in group i would be if it had the same exposure as the reference group, adjusting for any differences in confounder profiles.

9 Adjusted RR here refers to the adjusted relative risk value reported in the included studies.

10 These are actually the same data from Table C-6, but instead of presenting expected numbers, the sample sizes for the groups are shown, so as to illustrate the type of adjustment for cumulative incidence studies.

11 “Unknowns” in the sense that the effective counts that we desire are unknown to us and will result in values for Cases(i) and N(i) for I = 0, …, n. N = N(0) + … + N(n).

12 Coincidently, the effective cases in Table C-7 and Table C-8 are very similar. That is the case because the effective count calculation in those two instances were based on the same data (just treated differently, according to the assumption about whether they are incidence rate or cumulative incidence data).

13 EPA could have fixed the proportion for control in any group, but the focus on the referent group makes sense given the fact that it is the only group for which its expected value is independent of those in the other groups. As discussed in Table C-19.

14 Informal observation for the studies considered in the bladder cancer dose-response meta-analysis suggested that fixing the number of cases and proportion of controls in the referent group did a pretty good job of matching the other control proportions.

15 Note that this implies that the prospective “intercept,” α*, cannot be estimated without knowledge of the disease prevalence Pr(D = 1).

16 The parameters μ and σ^2^ are the log-scale mean and variance, respectively, for the assumed lognormal distribution defining h(X).

17 Equivalently, it is based on the referent group expected number, which equals n_1_*θ.

18 The referent group was not used as part of the observations used for the Bayesian updating, because it was used to define the prior for μ^′^_1_ .

19 For computational purposes, 85 years was used to define the upper limit for lifetime risk calculations.

20 This analysis was done using a different dataset of twelve bladder cancer studies than the main analysis and a prior estimate of the U.S. background dose. As described in the main assessment and previous section, the current U.S. background dose estimate is 0.0365 µg/kg-day and the dataset for the main analysis is listed in Table C-25.

21 This does not include the model having p_1_ = p_2_ = 0.

22 And also because of difficulties getting the double Hill models to converge when additional constraints were imposed via prior specifications.

23 Betancourt (2018). https://arxiv.org/pdf/1701.02434.pdf.

24 That is true if the weights were based on standard BIC/2 type weights.

25 The BIC is defined as -2*LL + k*ln(n), where LL is the is the log-likelihood of interest (here we are considering the posterior log-likelihood, either the maximum, which would be the “traditional” approach, or the mean). k is the number of parameters and n is the sample size. For the data set under consideration, n = 47; ln(n) = 3.85. Thus, for a fractional polynomial model (with k = 16) to have a lower BIC than the linear model (with k = 15), the LL would have to be 1.925 (=3.85/2) greater than that of the linear model (lower BIC is better)

26 Note that the dataset used in this sensitivity analysis consisted of twelve bladder cancer studies and differed from the set of eleven studies used in the main analysis (see Table C-25).

27 Corresponds to the target average proposal acceptance probability which is inversely related to the numerical integrator “step size” employed in Stan Hamiltonian MC.

28 Betancourt (2018). https://arxiv.org/pdf/1701.02434.pdf.

29 Details of the dose-response meta-analyses using low and high dose estimates are available from the arsenic dose-response supplemental files (U.S. EPA, 2025), which are accompanied by an explanatory structured workflow, outline, and variable dictionary (U.S. EPA, 2024b).

30 Corresponds to the target average proposal acceptance probability which is inversely related to the numerical integrator “step size” employed in Stan Hamiltonian MC.

31 Betancourt (2018). https://arxiv.org/pdf/1701.02434.pdf.

32 For diabetes, age-stratified morbidity and mortality values were not available; therefore, a summary estimate of the lifetime probability of developing type II diabetes was used instead.

33 Corresponds to the target average proposal acceptance probability which is inversely related to the numerical integrator “step size” employed in Stan Hamiltonian MC.

34 Betancourt (2018). https://arxiv.org/pdf/1701.02434.pdf.

35 For IHD, age-stratified morbidity and mortality values were not available; therefore, a summary estimate of the lifetime probability of developing these health outcomes were used instead.

36 Lloyd-Jones et al. (1999) reported lifetime risks of IHD (CHD) at an index age of 40 years for men (48.6%) and women (31.7%) enrolled in large Framingham Heart Study.

37 This study is not included in the EPA dose-response meta-analysis for these reasons and also because it combined populations with very different exposure scenarios (e.g., tap water systems were installed to replace well water in the 1970s in southwestern Taiwan versus in the 1990s in northeastern Taiwan).

38 Moon et al. (2017) estimated the pooled association between log-transformed water arsenic (log-linear) and restricted cubic splines of log-transformed water arsenic (non-linear) and the relative risk of each CVD endpoint. They modeled log relative risk of each CVD endpoint, assuming both a constant log-linear association (log-transformed arsenic concentrations) and a flexible non-linear association (restricted cubic splines with knots at the 10th, 50th and 90th percentiles of log-transformed arsenic).

39 EPA used a reference exposure of 1.5 µg /L and Moon et al. (2017) used a reference exposure of 10 µg/L.

40 Corresponds to the target average proposal acceptance probability which is inversely related to the numerical integrator “step size” employed in Stan Hamiltonian MC.

41 Betancourt (2018). https://arxiv.org/pdf/1701.02434.pdf.