# APPENDIX B HAZARD EVALUATION

## B.1 STUDY EVALUATION: DRAFT (NTP, 2013) RISK OF BIAS QUESTIONS AND ASSESSMENT-SPECIFIC CLARIFICATIONS EXAMPLE

Table B-1 Risk of bias questions and rating guidelines—epidemiological studies

1. Was administered dose or exposure level adequately randomized?
++ | OHAT:; Human Controlled Trial: There is direct evidence that subjects were allocated to any study group including controls using a method with a random component. Acceptable methods of randomization include referring to a random number table, using a computer random number generator, coin tossing, shuffling cards, or envelopes, throwing dice, or drawing of lots (Higgins and Green, 2011). Restricted randomization (e.g., blocked randomization) to ensure particular allocation ratios will be considered low risk of bias. Similarly, stratified randomization and minimization approaches that attempt to minimize imbalance between groups on important prognostic factors (e.g., body weight) will be considered acceptable.; Assessment-specific Clarification:; None.
+ | OHAT:; Human Controlled Trial: There is indirect evidence that subjects were allocated to study groups using a method with a random component (i.e., authors state that allocation was random, without description of the method used) OR it is deemed that allocation without a clearly random component during the study would not appreciably bias results. For example, approaches such as biased coin or urn randomization, replacement randomization, mixed randomization, and maximal randomization may require consultation with a statistician to determine risk of bias rating (Higgins and Green, 2011).; Assessment-specific Clarification:; None.
− | OHAT:; Human Controlled Trial: There is indirect evidence that subjects were allocated to study groups using a method with a non-random component OR there is insufficient information provided about how subjects were allocated to study groups. Non-random allocation methods may be systematic but have the potential to allow participants or researchers to anticipate the allocation to study groups. Such “quasi-random” methods include alternation, assignment based on date of birth, case record number, or date of presentation to study (Higgins and Green, 2011).; Assessment-specific Clarification:; None.
−− | OHAT:; Human Controlled Trial: There is direct evidence that subjects were allocated to study groups using a non-random method including judgment of the clinician, preference of the participant, the results of a laboratory test or a series of tests, or availability of the intervention (Higgins and Green, 2011).; Assessment-specific Clarification:; None.
2. Was allocation to study groups adequately concealed?
++ | OHAT:; Human Controlled Trial: There is direct evidence that at the time of recruitment the research personnel and subjects did not know what study group subjects were allocated to, and it is unlikely that they could have broken the blinding of allocation until after recruitment was complete and irrevocable. Methods used to ensure allocation concealment include central allocation (including telephone, web-based and pharmacy-controlled randomization); sequentially numbered drug containers of identical appearance; sequentially numbered, opaque, sealed envelopes; or equivalent methods.; Assessment-specific Clarification:; None.
+ | OHAT:; Human Controlled Trial: There is indirect evidence that the research personnel and subjects did not know what study group subjects were allocated to OR it is deemed that lack of adequate allocation concealment would not appreciably bias results.; Assessment-specific Clarification:; None.
− | OHAT:; Human Controlled Trial: There is indirect evidence that at the time of recruitment it was possible for the research personnel and subjects to know what study group subjects were allocated to, or it is likely that they could have broken the blinding of allocation before recruitment was complete and irrevocable OR there is insufficient information provided about allocation to study groups.; Note: Inadequate methods include using an open random allocation schedule (e.g., a list of random numbers), assignment envelopes used without appropriate safeguards (e.g., if envelopes were unsealed or nonopaque or not sequentially numbered), alternation or rotation; date of birth; case record number; or any other explicitly unconcealed procedure. For example, if the use of assignment envelopes is described, but it remains unclear whether envelopes were sequentially numbered, opaque, and sealed.; Assessment-specific Clarification:; None.
−− | OHAT:; Human Controlled Trial: There is direct evidence that at the time of recruitment it was possible for the research personnel and subjects to know what study group subjects were allocated to, or it is likely that they could have broken the blinding of allocation before recruitment was complete and irrevocable.; Assessment-specific Clarification:; None.
3. Were the comparison groups appropriate?
++ | OHAT:; Cohort, Cross-sectional: There is direct evidence that subjects (both exposed and non-exposed) were similar (e.g., recruited from the same eligible population, recruited with the same method of ascertainment using the same inclusion and exclusion criteria, and were of similar age and health status), recruited within the same time frame, and had the similar participation/response rates.; Case-Control: There is direct evidence that cases and controls were similar (e.g., recruited from the same eligible population including being of similar age, gender, ethnicity, and eligibility criteria other than outcome of interest as appropriate), recruited within the same time frame, and controls are described as having no history of the outcome. Note: A study will be considered low risk of bias if baseline characteristics of groups differed, but these differences were considered as potential confounding or stratification variables (see question #4).; Assessment-specific Clarification:; Ecological and Semi-individual: For ecological studies, a table of information or text on potential differences in characteristics that could bias results is provided, and these characteristics are adjusted for as potential confounders. There is direct evidence that subjects (both exposure groups and referent groups) were similar (e.g., of similar geographic region, ethnicity, socioeconomic status, etc.) OR baseline characteristics of groups differed but these differences were considered as potential confounding or stratification variables in analyses (see question #4).; Additional Guidance:; Comparison groups selected adequately. Study provides table of subject characteristics by exposure levels and/or by case status. Cross-sectional studies can be considered low risk of bias if a general table of subject characteristics is provided, and analyses are adjusted for confounders.
+ | OHAT:; Cohort, Cross-sectional: There is indirect evidence that subjects (both exposed and non-exposed) were similar (e.g., recruited from the same eligible population, recruited with the same method of ascertainment using the same inclusion and exclusion criteria, and were of similar age and health status), recruited within the same time frame, and had the similar participation/response rates OR differences between groups would not appreciably bias results.; Case-Control: There is indirect evidence that cases and controls were similar (e.g., recruited from the same eligible population, recruited with the same method of ascertainment using the same inclusion and exclusion criteria, and were of similar age), recruited within the same time frame, and controls are described as having no history of the outcome OR differences between cases and controls would not appreciably bias results.; Assessment-specific Clarification:; Ecological and Semi-individual: There is indirect evidence that subjects (both exposure groups and referent groups) were similar (e.g., of similar geographic region, ethnicity, socioeconomic status) OR differences between groups would not appreciably bias results.; Additional Guidance:; Recruitment methods stated to be similar, but no table of information or text provided on potential differences in study subjects’ characteristics that could bias results, OR no breakdown of subject characteristics by exposure group (or by case status) to display potential differences. For ecological studies, groups are stated to be similar, but no table of information or text is provided on potential characteristic differences that could bias results.
− | OHAT:; Cohort, Cross-sectional: There is indirect evidence that subjects (both exposed and non-exposed) were not similar, recruited within very different time frames, or had very different participation/response rates OR there is insufficient information provided about the comparison group including a different rate of non-response without an explanation.; Case-Control: There is direct evidence that controls were drawn from a very dissimilar population than cases or recruited within very different time frames OR there is insufficient information provided about the appropriateness of controls including rate of response reported for cases only.; Assessment-specific Clarification:; Ecological and Semi-individual: There is indirect evidence that subjects (both exposure groups and referent groups) were not similar (e.g., of similar geographic region, ethnicity, socioeconomic status) OR there is insufficient information provided about the appropriateness of comparison groups.
−− | OHAT:; Cohort, Cross-sectional: There is direct evidence that subjects (both exposed and non-exposed) were not similar, recruited within very different time frames, or had very different participation/response rates.; Case-Control: There is direct evidence that controls were drawn from a very dissimilar population than cases or recruited within very different time frames.; Assessment-specific Clarification:; Ecological and Semi-individual: There is direct evidence that subjects (both exposure groups and referent groups) were not similar (e.g., of similar geographic region, ethnicity, socioeconomic status).; Additional Guidance:; At least one known difference between the groups was not accounted for (e.g., the study authors acknowledged that the groups were different with respect to a variable that is a potential confounder not considered in the analysis) OR recruitment methods were very different (e.g., recruitment completed during different time frames, different criteria were used for recruitment).
4. Did the study design or analysis account for important confounding and modifying variables?
++ | OHAT:; Human Controlled Trial, Cohort, Cross-sectional, Case Series/Report: There is direct evidence that appropriate adjustments or explicit considerations were made for primary covariates and confounders in the final analyses through the use of statistical models to reduce research-specific bias including standardization, case matching, adjustment in multivariate model, stratification, propensity scoring, or other methods were appropriately justified. Acceptable consideration of appropriate adjustment factors includes cases when the factor is not included in the final adjustment model because the author conducted analyses that indicated it did not need to be included.; Case-Control: There is direct evidence that appropriate adjustments were made for primary covariates and confounders in the final analyses through the use of statistical models to reduce research specific bias including standardization, matching of cases and controls, adjustment in multivariate model, stratification, propensity scoring, or other methods were appropriately justified.; Assessment-specific Clarification:; Ecological and Semi-individual: There is direct evidence that appropriate adjustments or explicit considerations were made for covariates and confounders in the final analyses through the use of statistical models (e.g., standardization, multivariate adjustment). Acceptable consideration of appropriate adjustment factors includes cases when the factor is not included in the final adjustment model because the author conducted analyses that indicated it did not need to be included.; Additional Guidance:; Study adjusted for or addressed important potential confounders. Age, gender, education, and socioeconomic status are potential confounders that need to be addressed and considered in the study design or analyses. In addition, specific important confounders for this assessment depend on the health outcome and include smoking for lung cancer, sun exposure for skin lesions, and alcohol drinking for hepatic outcomes. Other confounders might also be judged important for certain health outcomes. A low risk of bias rating was assigned for this question if potential confounders deemed important were adequately addressed (e.g., distribution of variables was compared between groups, and there was no statistically significant difference).
+ | OHAT:; Human Controlled Trial, Cohort, Case-Control, Cross-sectional, Case Series/Report: There is indirect evidence that appropriate adjustments were made for most primary covariates and confounders OR it is deemed that not considering or only considering a partial list of covariates or confounders in the final analyses would not appreciably bias results.; Assessment-specific Clarification:; Ecological and Semi-individual: There is indirect evidence that appropriate adjustments were made for most covariates and confounders OR it is deemed that not considering or only considering a partial list of covariates or confounders in the final analyses would not appreciably bias results.; Additional Guidance:; Study adjusted only for some important potential confounders (e.g., sex and age), but it is likely that other confounders were present and not addressed (i.e., minimal number of confounders addressed).
− | OHAT:; Human Controlled Trial, Cohort, Cross-sectional, Case Series/Report: There is indirect evidence that the distribution of primary covariates and known confounders differed between the groups and was not appropriately adjusted for in the final analyses OR there is insufficient information provided about the distribution of known confounders.; Case-Control: There is indirect evidence that the distribution of primary covariates and known confounders differed between cases and controls and was not investigated further OR there is insufficient information provided about the distribution of known confounders in cases and controls.; Assessment-specific Clarification:; Ecological and Semi-individual: There is indirect evidence that the distribution of covariates and known confounders differed between the groups and was not appropriately adjusted for in the final analyses OR there is insufficient information provided about the distribution of known confounders.; Additional Guidance:; Design or analysis did not adjust for important potential confounders. Adjustments were made for some potential confounders, but at least one major confounder was not addressed (e.g., no adjustment for smoking when evaluating lung cancer, no adjustment for sun exposure when evaluating skin cancer).
−− | OHAT:; Human Controlled Trial, Cohort, Cross-sectional, Case Series/Report: There is direct evidence that the distribution of primary covariates and known confounders differed between the groups, confounding was demonstrated, and was not appropriately adjusted for in the final analyses.; Case-Control: There is direct evidence that the distribution of primary covariates and known confounders differed between cases and controls, confounding was demonstrated, but was not appropriately adjusted for in the final analyses.; Assessment-specific Clarification:; Ecological and Semi-individual: Same as OHAT Human Controlled Trial, Cohort, Cross-sectional, and Case Series/report criteria.; Additional Guidance:; None.
5. Did researchers adjust or control for other exposures that are anticipated to bias results?
++ | OHAT:; Human Controlled Trial: There is direct evidence that other exposures anticipated to bias results were not present or were appropriately adjusted for.; Cohort, Case- Control, Cross-sectional, Case Series/Report: There is direct evidence that other exposures anticipated to bias results were not present or were appropriately adjusted for. For occupational studies or studies of contaminated sites, other chemical exposures known to be associated with those settings were appropriately considered.; Assessment-specific Clarification:; Ecological and Semi-individual: Same as OHAT Human Controlled Trial criteria.; Additional Guidance:; Researchers adjusted for other chemicals or accounted for occupational exposures likely to be associated with the outcome.
+ | OHAT:; Human Controlled Trial, Cohort, Case-Control, Cross-sectional, Case Series/Report: There is indirect evidence that other co-exposures anticipated to bias results were not present or were appropriately adjusted for OR it is deemed that co-exposures present would not appreciably bias results. Note, as discussed above, this includes insufficient information provided on co-exposures in general population studies.; Assessment-specific Clarification:; Ecological and Semi-individual: Same as OHAT criteria.; Additional Guidance:; No evidence that co-exposures were addressed as confounders, but other specific chemicals or occupational exposures were addressed.
− | OHAT:; Human Controlled Trial: There is indirect evidence that the control group may have received the treatment or there was an unbalanced provision of additional co-exposures, which were not appropriately adjusted for.; Cohort, Cross-sectional, Case Series/Report: There is indirect evidence that there was an unbalanced provision of additional co-exposures across the primary study groups, which were not appropriately adjusted for OR there is insufficient information provided about co-exposures in occupational studies or studies of contaminated sites where high exposures to other chemical exposures would have been reasonably anticipated.; Case-Control: There is indirect evidence that there was an unbalanced provision of additional co-exposures across cases and controls, which were not appropriately adjusted for OR there is insufficient information provided about co-exposures in occupational studies or studies of contaminated sites where high exposures to other chemical exposures would have been reasonably anticipated.; Assessment-specific Clarification:; Ecological and Semi-individual: There is indirect evidence that there was an unbalanced provision of additional co-exposures, which were not appropriately adjusted for OR there is insufficient information provided about co-exposures in studies of contaminated sites where high exposures to other chemical exposures would have been reasonably anticipated.; Additional Guidance:; There is evidence that co-exposures might not have been addressed. Examples include a study population with farmers and/or other types of workers but occupational co-exposures (e.g., to pesticides) not addressed; or a study with known co-exposures, but the relevance of the co-exposure to arsenic effects is unknown, or it is not clear if other compounds were adjusted for in the analyses.
−− | OHAT:; Human Controlled Trial: There is direct evidence that the control group received the treatment or there was an unbalanced provision of additional co-exposures, which were not appropriately adjusted for.; Cohort, Cross-sectional, Case Series/Report: There is direct evidence that there was an unbalanced provision of additional co-exposures across the primary study groups, which were not appropriately adjusted for.; Case-Control: There is direct evidence that there was an unbalanced provision of additional co-exposures across cases and controls, which were not appropriately adjusted for.; Assessment-specific Clarification:; Ecological and Semi-individual: There is direct evidence that there was an unbalanced provision of additional co-exposures, which were not appropriately adjusted for.; Additional Guidance:; Known differential exposure to other chemical/pollutant also associated with the health outcome of interest occurred with arsenic, and exposure was not addressed by study authors. An example is a study of copper smelter workers where the study authors either (a) list other chemicals likely to be associated with the health outcome that the subjects were exposed to, or (b) provide levels of the other compounds, AND there were statistically significant differences related to the arsenic exposure that were not addressed. Such differences might have resulted from differential exposure to another compound or arsenic; thus, it cannot be determined which exposure impacted the results.
6. Were experimental conditions identical across study groups?
NA | NA
7. Did researchers adhere to the protocol?
++ | OHAT:; Human Controlled Trial, Cohort, Case-Control, Cross-sectional, Case Series/Report: There is direct evidence that there were no deviations from the protocol (i.e., the study report explicitly provides this level of detail).; Assessment-specific Clarification:; Ecological and Semi-individual: Same as OHAT criteria.; Additional Guidance:; None.
+ | OHAT:; Human Controlled Trial, Cohort, Case-Control, Cross-sectional, Case Series/Report: There is indirect evidence that there were no deviations from the protocol (i.e., authors did not report any deviations) OR deviations from the protocol are described and it is deemed that they would not appreciably bias results.; Assessment-specific Clarification:; Ecological and Semi-individual: Same as OHAT criteria.; Additional Guidance:; Taking into consideration typical reporting practices, it seems unlikely that deviations from the protocol will be explicitly reported in most studies. Thus, unless stated otherwise by the authors (i.e., evidence of deviation is reported), or it is clear from the study report that deviations from the planned approach occurred, assume that no deviations occurred. It is anticipated that this approach will result in a rating of “probably low risk of bias” (+) for most studies. If there are deviations, the rating reflects how the deviations changed direction, magnitude, and/or significance of the results.
− | OHAT:; Human Controlled Trial, Cohort, Case-Control, Cross-sectional, Case Series/report: There is indirect evidence that there were large deviations from the protocol as outlined in the methods or study report.; Assessment-specific Clarification:; Ecological and Semi-individual: Same as OHAT criteria.; Additional Guidance:; None.
−− | OHAT:; Human Controlled Trial, Cohort, Case-Control, Cross-sectional, Case Series/Report: There is direct evidence that there were large deviations from the protocol as outlined in the methods or study report.; Assessment-specific Clarification:; Ecological and Semi-individual: Same as OHAT criteria.; Additional Guidance:; None.
8. Were the research personnel and human subjects blinded to the study group during the study?
++ | OHAT:; Human Controlled Trial: There is direct evidence that the subjects and research personnel were adequately blinded to study group, and it is unlikely that they could have broken the blinding during the study. Methods used to ensure blinding include central allocation, sequentially numbered drug containers of identical appearance; sequentially numbered, opaque, sealed envelopes; or equivalent methods.; Assessment-specific Clarification:; None.
+ | OHAT:; Human Controlled Trial: There is indirect evidence that the research personnel and subjects were adequately blinded to study group, and it is unlikely that they could have broken the blinding during the study, OR it is deemed that lack of adequate blinding during the study would not appreciably bias results.; Assessment-specific Clarification:; None.
− | OHAT:; Human Controlled Trial: There is indirect evidence that it was possible for research personnel or subjects to infer the study group, OR there is insufficient information provided about blinding of study group. Inadequate methods include using an open random allocation schedule (e.g., a list of random numbers), assignment envelopes used without appropriate safeguards (e.g., if envelopes were unsealed or nonopaque or not sequentially numbered), alternation or rotation; date of birth; case record number; or any other explicitly unconcealed procedure. For example, if the use of assignment envelopes is described, but it remains unclear whether envelopes were sequentially numbered, opaque, and sealed.; Assessment-specific Clarification:; None.
−− | OHAT:; Human Controlled Trial: There is direct evidence for lack of adequate blinding of the study group including no blinding or incomplete blinding of research personnel and subjects. For some treatments, such as behavioral interventions, allocation to study groups cannot be concealed.; Assessment-specific Clarification:; None.
9. Were outcome data complete without attrition or exclusion from analysis?
++ | OHAT:; Human Controlled Trial: There is direct evidence that there was no loss of subjects during the study and outcome data were complete OR loss of subjects (i.e., incomplete outcome data) was adequately addressed and reasons were documented when human subjects were removed from a study. Review authors should be confident that the participants included in the analysis are exactly those who were randomized into the trial. Acceptable handling of subject attrition includes: very little missing outcome data [less than 10% in each group (Genaidy et al., 2007)]; reasons for missing subjects unlikely to be related to outcome (for survival data, censoring unlikely to be introducing bias); missing outcome data balanced in numbers across study groups, with similar reasons for missing data across groups OR analyses (such as intention-to-treat analysis) in which missing data have been imputed using appropriate methods (ensuring that the characteristics of subjects lost to follow up or with unavailable records are described in an identical way and are not significantly different from those of the study participants).; NOTE: Participants randomized but subsequently found not to be eligible need not always be considered as having missing outcome data (Higgins and Green, 2011). Cohort: There is direct evidence that loss of subjects (i.e., incomplete outcome data) was adequately addressed and reasons were documented when human subjects were removed from a study. Acceptable handling of subject attrition includes: very little missing outcome data; reasons for missing subjects unlikely to be related to outcome (for survival data, censoring unlikely to be introducing bias); missing outcome data balanced in numbers across study groups, with similar reasons for missing data across groups; OR missing data have been imputed using appropriate methods, AND characteristics of subjects lost to follow up or with unavailable records are described in an identical way and are not significantly different from those of the study participants.; Case-Control, Cross-sectional: There is direct evidence that exclusion of subjects from analyses was adequately addressed, and reasons were documented when subjects were removed from the study or excluded from analyses.; Assessment-specific Clarification:; Ecological and Semi-individual: There is direct evidence that there was no loss of subjects (e.g., due to moving or migration) or data during the study and outcome data were complete OR incomplete outcome data were adequately addressed AND characteristics of subjects lost to follow up or with unavailable records are described in an identical way and are not significantly different from those of the study participants.; Additional Guidance:; There are no reported data lost to attrition, and the numbers in the results tables sum to the total number of subjects, OR less than 10% of data are missing, OR there are some missing outcome data but study report clearly identifies missing data and how it was handled (e.g., loss to follow-up for a cohort study is determined to be minimal if there are some missing data for either the exposure or outcome for certain subjects at a specific time measured and the authors clearly explain what happened to everyone and which results were used in the analyses). For ecological studies specifically, there are no reported data lost to attrition OR there are some missing data but study report clearly identifies missing data and how they were handled (e.g., migration in and out of study area and residence location within study area were tracked and accounted for or references provided to verify that population migration within or in/out of study area is not a concern for this population), and characteristics of subjects lost to attrition do not differ significantly from those included in study.
+ | OHAT:; Human Controlled Trial: There is indirect evidence that loss of subjects (i.e., incomplete outcome data) was adequately addressed and reasons were documented when human subjects were removed from a study OR it is deemed that the proportion lost to follow-up would not appreciably bias results [less than 20% in each group (Genaidy et al., 2007)]. This would include reports of no statistical differences in characteristics of subjects lost to follow up or with unavailable records from those of the study participants. Generally, the higher the ratio of participants with missing data to participants with events, the greater potential there is for bias. For studies with a long duration of follow-up, some withdrawals for such reasons are inevitable. Cohort: There is indirect evidence that loss of subjects (i.e., incomplete outcome data) was adequately addressed and reasons were documented when human subjects were removed from a study OR it is deemed that the proportion lost to follow-up would not appreciably bias results. This would include reports of no statistical differences in characteristics of subjects lost to follow up or with unavailable records from those of the study participants. Generally, the higher the ratio of participants with missing data to participants with events, the greater potential there is for bias. For studies with a long duration of follow-up, some withdrawals for such reasons are inevitable.; Case-Control, Cross-sectional: There is indirect evidence that exclusion of subjects from analyses was adequately addressed, and reasons were documented when subjects were removed from the study or excluded from analyses.; Assessment-specific Clarification:; Ecological and Semi-individual: There is indirect evidence that there was no loss of subjects (e.g., due to migration during the study) and outcome data were complete OR it is deemed that the proportion of subjects lost to follow-up would not appreciably bias results. This would include reports of no statistical differences in characteristics of subjects lost to follow up or with unavailable records of outcomes. For studies with a long duration of follow-up, some withdrawals for such reasons are inevitable.; Additional Guidance:; No direct evidence of loss to follow-up, attrition, or loss of subjects due to migration/moving provided. The tables of results do not include the number of subjects and it is not stated that there was any loss data missing OR there appear to be no or very few missing data, OR in a cohort study, there is no mention of loss to follow-up.
− | OHAT:; Human Controlled Trial: There is indirect evidence that loss of subjects (i.e., incomplete outcome data) was unacceptably large [greater than 20% in each group (Genaidy et al., 2007)] and not adequately addressed OR there is insufficient information provided about numbers of subjects lost to follow-up.; Cohort: There is indirect evidence that loss of subjects (i.e., incomplete outcome data) was unacceptably large and not adequately addressed OR there is insufficient information provided about numbers of subjects lost to follow-up.; Case-Control, Cross-sectional: There is indirect evidence that exclusion of subjects from analyses was not adequately addressed, OR there is insufficient information provided about why subjects were removed from the study or excluded from analyses.; Assessment-specific Clarification:; Ecological and Semi-individual: There is indirect evidence that incomplete outcome data (e.g., due to subject migration or moving) were unacceptably large [greater than 20% in each group (Genaidy et al., 2007)] and not adequately addressed OR there is insufficient information provided about missing outcome data.; Additional Guidance:; Missing outcome data with no explanation of why data were missing, and it is unclear from the characteristics table or other information provided in the report why the data might be missing.
−− | OHAT:; Human Controlled Trial, Cohort: There is direct evidence that loss of subjects (i.e., incomplete outcome data) was unacceptably large and not adequately addressed. Unacceptable handling of subject attrition includes reason for missing outcome data likely to be related to true outcome, with either imbalance in numbers or reasons for missing data across study groups, or potentially inappropriate application of imputation.; Case-Control, Cross-sectional: There is direct evidence that exclusion of subjects from analyses was not adequately addressed. Unacceptable handling of subject exclusion from analyses includes reason for exclusion likely to be related to true outcome, with either imbalance in numbers or reasons for exclusion across study groups.; Assessment-specific Clarification:; Ecological and Semi-individual: There is direct evidence that incomplete outcome data were unacceptably large and not adequately addressed OR that characteristics of subjects lost to attrition were significantly different from those included in study.; Additional Guidance:; The missing outcome data are clearly related to exposure (more missing data for exposed compared to unexposed groups), but the study authors do not address why. For ecological studies, there is unacceptable handling of subject migration into and out of study area or subject residence locations within study area.
10. Were the outcome assessors blinded to study group or exposure level?
++ | OHAT:; Human Controlled Trial: There is direct evidence that the outcome assessors (including study subjects, if outcomes were self-reported) were adequately blinded to the study group, and it is unlikely that they could have broken the blinding prior to reporting outcomes.; Cohort, Cross-sectional, Case Series/Report: There is direct evidence that the outcome assessors (including study subjects, if outcomes were self-reported) were adequately blinded to the exposure level, and it is unlikely that they could have broken the blinding prior to reporting outcomes.; Case-Control: There is direct evidence that the outcome assessors (including study subjects if outcomes were self-reported) were adequately blinded to the exposure level when reporting outcomes.; Assessment-specific Clarification:; Ecological and Semi-individual: Same as OHAT Cohort, Cross-sectional, and Case Series/Report criteria.; Additional Guidance:; The study report states that outcome assessors were blinded to subjects’ exposure levels, OR in a case-control study, researchers who assigned exposure levels based on drinking water level were blinded to the case/control status of the participant.
+ | OHAT:; Human Controlled Trial: There is indirect evidence that the outcome assessors (including study subjects, if outcomes were self-reported) were adequately blinded to the study group, and it is unlikely that they could have broken the blinding prior to reporting outcomes, OR it is deemed that lack of adequate blinding of outcome assessors would not appreciably bias results, which may vary by outcome (i.e., blinding is especially important for subjective measures).; Cohort, Cross-sectional, Case Series/Report: There is indirect evidence that the outcome assessors were adequately blinded to the exposure level, and it is unlikely that they could have broken the blinding prior to reporting outcomes OR it is deemed that lack of adequate blinding of outcome assessors would not appreciably bias results (including that subjects self-reporting outcomes were likely not aware of reported links between the exposure and outcome lack of blinding is unlikely to bias a particular outcome).; Case-Control: There is direct evidence that the outcome assessors were adequately blinded to the exposure level when reporting outcomes OR it is deemed that lack of adequate blinding of outcome assessors would not appreciably bias results (including that subjects self-reporting outcomes were likely not aware of reported links between the exposure and outcome, or lack of blinding is unlikely to bias a particular outcome).; Assessment-specific Clarification:; Ecological and Semi-individual: Same as OHAT Human Controlled Trial criteria.; Additional Guidance:; No direct statement that outcome assessors were blind, but it is likely that they were (e.g., pathologists conducting histopathology on the tissue would most likely be blind to the exposure status), OR outcomes were assessed using an automated instrument, making it unlikely that the results would be biased since automated instrument would not be biased.
− | OHAT:; Human Controlled Trial: There is indirect evidence that it was possible for outcome assessors (including study subjects if outcomes were self-reported) to infer the study group prior to reporting outcomes, OR there is insufficient information provided about blinding of outcome assessors.; Cohort, Cross-sectional, Case Series/Report: There is indirect evidence that it was possible for outcome assessors to infer the exposure level prior to reporting outcomes (including that subjects self-reporting outcomes were likely aware of reported links between the exposure and outcome) OR there is insufficient information provided about blinding of outcome assessors.; Case-Control: There is indirect evidence that it was possible for outcome assessors to infer the exposure level prior to reporting outcomes (including that subjects self-reporting outcomes were likely aware of reported links between the exposure and outcome) OR there is insufficient information provided about blinding of outcome assessors.; Assessment-specific Clarification:; Ecological and Semi-individual: Same as OHAT Case-Control criteria.; Additional Guidance:; Not enough information to determine if outcome assessors were blind to exposure status and possibility exists that they could have knowledge (e.g., it is a cohort and exposure was assessed prior to outcome), OR likely that outcome assessors were aware of exposure, but not necessarily level of exposure (e.g., outcome was assessed in subject’s home, which is in either the control village or exposed village, but the study report evaluated different exposure levels in village so that when assessing the outcome, assessors would be aware that subjects were exposed or controls but not exact exposure level).
−− | OHAT:; Human Controlled Trial: There is direct evidence for lack of adequate blinding of outcome assessors (including study subjects if outcomes were self-reported), including no blinding or incomplete blinding.; Cohort, Cross-sectional, Case Series/Report: There is direct evidence that outcome assessors were aware of the exposure level prior to reporting outcomes (including that subjects self-reporting outcomes were aware of reported links between the exposure and outcome).; Case-Control: There is direct evidence that outcome assessors were aware of the exposure level prior to reporting outcomes (including that subjects self-reporting outcomes were aware of reported links between the exposure and outcome).; Assessment-specific Clarification:; Ecological and Semi-individual: Same as OHAT Case-Control criteria.; Additional Guidance:; There is direct evidence that outcome assessor knew exposure status (e.g., same situation as above with outcome assessed in the village, but the report only evaluates exposure as “exposed versus unexposed,” with no arsenic levels measured).
11. Were confounding variables assessed consistently across groups using valid and reliable measures?
++ | OHAT:; Human Controlled Trial, Cohort, Case-Control, Cross-sectional, Case Series/Report: There is direct evidence that primary covariates and confounders were assessed using valid and reliable measurements.; Assessment-specific Clarification:; Ecological and Semi-individual: There is direct evidence that group- or individual-level primary covariates and confounders were assessed using valid and reliable measurements.; Additional Guidance:; Methods provide specific details on how confounders were measured (e.g., for body weight, details provided to indicate precision of measurement instrument and, ideally, calibration of instrument). Validated or pretested questionnaires used, and there was low potential for interviewer bias.
+ | OHAT:; Human Controlled Trial, Cohort, Case-Control, Cross-sectional, Case Series/Report: There is indirect evidence that primary covariates and confounders were assessed using valid and reliable measurements OR it is deemed that the measures used would not appreciably bias results (i.e., the authors justified the validity of the measures from previously published research).; Assessment-specific Clarification:; Ecological and Semi-individual: There is indirect evidence that group- or individual-level primary covariates and confounders were assessed using valid and reliable measurements OR it is deemed that the measures used would not appreciably bias results (i.e., the authors justified the validity of the measures from previously published research).; Additional Guidance:; Self-administered questionnaire, OR questionnaire administered by a single interviewer for all subjects (thus eliminating the possibility for interviewer agreement bias), OR methods for assessing confounders were mixed (e.g., some methods well conducted and consistent, but others may have been obtained from questionnaires not stated to be validated).
− | OHAT:; Human Controlled Trial, Cohort, Case-Control, Cross-sectional, Case Series/Report: There is indirect evidence that primary covariates and confounders were assessed using measurements of unknown validity OR there is insufficient information provided about the measures used.; Assessment-specific Clarification:; Ecological and Semi-individual: There is indirect evidence that group- and individual-level primary covariates and confounders were assessed using measurements of unknown validity OR there is insufficient information provided about the measures used.; Additional Guidance:; Not enough details were provided on how the confounders were assessed. Questionnaire used and administered by several interviewers with no details on validity/reliability of the questionnaire or on consistency between the interviewers.
−− | OHAT:; Human Controlled Trial, Cohort, Case-Control, Cross-sectional, Case Series/Report: There is direct evidence that primary covariates and confounders were assessed using nonvalid measurements.; Assessment-specific Clarification:; Ecological and Semi-individual: There is direct evidence that group- or individual-level primary covariates and confounders were not assessed using valid and reliable measures.; Additional Guidance:; There is direct evidence of selective recall by disease status.
12. Can we be confident in the exposure characterization?
++ | OHAT:; Human Controlled Trial: There is direct or indirect evidence that the test material is confirmed as ≥99% pure (or impurities have been characterized and not considered to be of serious concern), and that the concentration, stability, and homogeneity of stock material and formulation have been verified as appropriate (Note: ≥99% purity value is considered achievable based on current advertised purity from Sigma-Aldrich); AND FOR INTERNAL DOSIMETRY STUDIES there is direct evidence that most data points for the aglycone, conjugated and/or total BPA are above the level of quantitation (LOQ) for the assay; AND the study utilized spiked samples to confirm assay performance and the stability of BPA and conjugated BPA in biological samples was appropriately addressed; AND studies took measures to assess potential BPA contamination that might have occurred during sample collection and analysis, including method blanks. Note: Use of method blanks is necessary to identify potential sources of contamination in blood and urine but cannot rule out all possible sources of contamination (Ye et al., 2012). The risk of contamination for blood-based measurements is likely higher than for urinary measurements in part because sterile plastic blood collection containers can increase the number of sources of contamination and because of higher levels of protein and lipid levels in blood versus urine. Preferred practices include (1) measurement of aglycone AND conjugated or total BPA for blood measurements, and (2) use of isotopically labeled BPA dosing material (e.g., deuterated) to avoid issues of contamination, although we will not “downgrade” if a study did not follow these preferred practices.; Cohort, Case-Control, Cross-sectional, Case Series/Report: There is direct evidence that most data points for the aglycone, conjugated and/or total BPA are above the level of quantitation (LOQ) for the assay; AND the study utilized spiked samples to confirm assay performance and the stability of BPA and conjugated BPA in biological samples was appropriately addressed; AND studies took measures to assess potential BPA contamination that might have occurred during sample collection and analysis including method blanks. Note: Use of method blanks is necessary to identify potential sources of contamination in blood and urine but cannot rule out all possible sources of contamination (Ye et al., 2012). The risk of contamination for blood-based measurements is likely higher than for urinary measurements in part because sterile plastic blood collection containers can increase the number of sources of contamination and because of higher levels of protein and lipid levels in blood versus urine. Preferred practices include (1) measurement of aglycone AND conjugated or total BPA for blood measurements, and (2) inclusion of multiple measurements of BPA because a single sample from an individual does not appear to be strong predictor of a subject’s exposure category. Mahalingaiah et al. (2008) analyzed samples from at least six repeat urinary BPA measurements from eight subjects. The sensitivity, specificity, and positive predictive value of a single urine sample to predict the highest BPA tertile were 0.64, 0.76, and 0.63, respectively. The positive predictive value increased to 0.85 when two samples were used to predict those individuals in the highest BPA tertile. Use of a single measurement in large sample size studies such as NHANES is less of an issue because the number of participants offsets potential concern for differential exposure misclassification. We will not downgrade if a study did not follow these preferred practices.; Assessment-specific Clarification:; Ecological and Semi-individual: This rating is not applicable. Only studies with individual-level exposure characterization can earn this rating. If individual-level exposure data are provided, the study is not an ecological study, and should be re-classified and rated according to other study-type ROB criteria.; Additional Guidance:; Single spot urine samples are reported for a large number of subjects (over 1,000), OR multiple (repeated) spot urine samples were reported. Individual-level drinking water levels (e.g., obtained from household tap or household well, but not village-level well) with methods well described, including reporting of levels of detection (LODs). Toenail and hair samples were cleaned, AND the recovery rate of the method or use of internal standards is reported. More than one arsenic exposure assessment (more than one matrix, and/or more than one measurement) and at least one of them is excellent (e.g., the large HEALS cohort and spot urine spot samples, in addition to village-level water arsenic measurements) and a correlation reported between the different measurements.
+ | OHAT:; Human Controlled Trial: There is direct or indirect evidence that purity was ≥98%, (or impurities have been characterized and not considered to be of serious concern, i.e., purity was independently confirmed by lab, purity is reported in paper or obtained through author query, or purity not reported but the source is listed and the supplier of the chemical provides documentation of the purity of the chemical; AND FOR INTERNAL DOSIMETRY STUDIES there is indirect evidence that most data points for the aglycone, conjugated and/or total BPA are above the level of quantitation (LOQ) for the assay, i.e., the central estimate (median, mean, geometric mean) is above the LOQ but results for individual data values are not presented or the presentation of variance estimates does not permit assessment of whether most data points are likely above the LOQ; AND the study utilized spiked samples to confirm assay performance and the stability of BPA and conjugated BPA in biological samples was appropriately addressed; AND studies took measures to assess potential BPA contamination that might have occurred during sample collection and analysis including method blanks.; Cohort, Case-Control, Cross-sectional, Case Series/Report: There is indirect evidence that most data points for the aglycone, conjugated and/or total BPA are above the level of quantitation (LOQ) for the assay, i.e., the central estimate (median, mean, geometric mean) is above the LOQ but results for individual data values are not presented or the presentation of variance estimates do not permit assessment of whether most data points are likely above the LOQ; AND the study utilized spiked samples to confirm assay performance and the stability of BPA and conjugated BPA in biological samples has been appropriately addressed; AND studies took measures to assess potential BPA contamination that might have occurred during sample collection and analysis including method blanks; OR use of questionnaire items where results of biomonitoring studies support the use of the questionnaire item(s) as an indicator of relative level of exposure; OR job description for occupational studies where levels in the work environment or results of biomonitoring studies support the use of job description as an indicator of relative level of exposure.; Assessment-specific Clarification:; Ecological and Semi-individual: There is direct or indirect evidence that the exposure to the chemical of concern was adequately characterized by appropriate measures and methods (e.g., adequate monitoring over time of multiple sources per exposure group, cumulative exposures based on historical changes in measured exposures, exposure measures taken for a moderate proportion of population).; Additional Guidance:; Single spot urine samples with a moderate number of subjects (i.e., hundreds or more). Adequate measurements and methods, but LODs are not provided. Exposure based on occupational title but supported by some arsenic monitoring (air, urine, or other biomarker). For ecological studies, drinking water levels were obtained from the smallest groups available (e.g., household or village level) with methods well described and monitoring over time to estimate cumulative exposure based on changes in arsenic concentrations, including reporting of LODs and residential durations.
− | OHAT:; Human Controlled Trial: Neither the source or purity of the chemical was reported in the study and information on purity could not be obtained through author query/vendor documentation; AND FOR INTERNAL DOSIMETRY STUDIES there is direct or indirect evidence that most data points for the aglycone, conjugated and/or total BPA are above the level of quantitation (LOQ) for the assay BUT no steps were taken to assess potential BPA contamination that might have occurred during sample collection and analysis; OR there is indirect or direct evidence that most individual data points for the aglycone, conjugated and/or total BPA are below the level of quantitation (LOQ) for the assay; OR method to measure BPA used ELISA, which is less accepted as providing quantitatively accurate values and because of potential uncharacterized antibody cross-reactivity with conjugates and endogenous components of sample matrices (Vandenberg et al., 2007; Chapin et al., 2008); Cohort, Case-Control, Cross-sectional, Case Series/Report: There is direct or indirect evidence that most data points for the aglycone, conjugated and/or total BPA are above the level of quantitation (LOQ) for the assay BUT no steps were taken to assess potential BPA contamination that might have occurred during sample collection and analysis; OR there is indirect or direct evidence that most individual data points for the aglycone, conjugated and/or total BPA are below the level of quantitation (LOQ) for the assay; OR method to measure BPA used ELISA, which leads to concern because of uncharacterized antibody cross-reactivity with conjugates and endogenous components of sample matrices (Vandenberg et al., 2007; Chapin et al., 2008); OR use of questionnaire items that are not supported by results of biomonitoring studies; OR job description for occupational studies that are not supported by information on levels in the work environment or results of biomonitoring studies; Assessment-specific Clarification:; Ecological and Semi-individual: There is indirect evidence that the chemical in question was not adequately characterized by appropriate measures and methods (e.g., no historical monitoring, isolated or remote-time samples taken to be representative of large areas, no cumulative exposures estimated).; Additional Guidance:; Exposure based on single spot urine sample for a limited number of subjects (less than 100), OR exposure based on occupational title with no arsenic monitoring, OR cumulative arsenic levels based on self-reported duration/resident history and group well-water measurements.
−− | OHAT:; Human Controlled Trial: There is indirect or direct evidence that purity was <98%; AND FOR INTERNAL DOSIMETRY STUDIES there is direct evidence of uncontrolled contamination.; Cohort, Case-Control, Cross-sectional, Case Series/Report: There is direct evidence of uncontrolled contamination; OR not reporting of methods used to assess exposure and this information could not be obtained through author query; OR self-report exposure.; Assessment-specific Clarification:; Ecological and Semi-individual: There is direct evidence that the chemical in question was not adequately characterized by appropriate measures and methods (e.g., no historical monitoring, isolated or remote-time samples taken to be representative of large areas, no cumulative exposures estimated), OR there is direct evidence of uncontrolled contamination, OR methods used to assess exposure not reported, OR self-reported exposure.; Additional Guidance:; No measured arsenic concentrations. Exposure assessed based on presence/absence of skin lesions OR self-reported duration of drinking water or living in a certain area OR lifetime cumulative arsenic exposure determined using self-reported information on residential history and drinking-water daily consumption rates, and village-level median arsenic concentration in drinking water.
13. Can we be confident in the outcome assessment?
++ | OHAT:; Human Controlled Trial, Cohort: There is direct evidence that the outcome was assessed using well-established methods, the “gold standard” or with validity and reliability >0.70 (Genaidy et al., 2007) and subjects had been followed for the same length of time in all study groups. Acceptable assessment methods will depend on the outcome, but examples of such methods may include objectively measured with diagnostic methods, measured by trained interviewers, obtained from registries (Shamliyan et al., 2010).; Case-Control: There is direct evidence that the outcome was assessed in cases using well-established methods (the gold standard) and subjects had been followed for the same length of time in all study groups.; Cross-sectional, Case Series/Report: There is direct evidence that the outcome was assessed using well-established methods (the gold standard).; Assessment-specific Clarification:; Ecological and Semi-individual: There is direct evidence that the outcome was assessed using well-established methods, the “gold standard” (e.g., individual-level outcome data were assessed, as in the case of semi-individual ecological studies) and subjects have been followed for the same length of time in all study groups. Acceptable assessment methods will depend on the outcome, but examples of such methods may include objectively measured with diagnostic methods, measured by trained interviewers, obtained from reliable registries or records.; Additional Guidance:; Cancer cases are histologically confirmed, OR data obtained from nationwide registry are accepted as valid and complete (e.g., Taiwan), OR outcome diagnosed by physician, OR outcome obtained from medical record data or validated with such data (if self-reported).
+ | OHAT:; Human Controlled Trial, Cohort: There is indirect evidence that the outcome was assessed using acceptable methods [i.e., deemed valid and reliable but not the gold standard or with validity and reliability ≥0.40 (Genaidy et al., 2007)] and subjects had been followed for the same length of time in all study groups OR it is deemed that the outcome assessment methods used would not appreciably bias results. Acceptable, but not ideal assessment methods will depend on the outcome, but examples of such methods may include proxy reporting of outcomes and mining of data collected for other purposes.; Case-Control: There is indirect evidence that the outcome was assessed in cases (i.e., case definition) using acceptable methods and subjects had been followed for the same length of time in all study groups OR it is deemed that the outcome assessment methods used would not appreciably bias results.; Cross-sectional, Case Series/Report: There is indirect evidence that the outcome was assessed using acceptable methods OR it is deemed that the outcome assessment methods used would not appreciably bias results.; Assessment-specific Clarification:; Ecological and Semi-individual: There is indirect evidence that the outcome was assessed using acceptable methods (i.e., deemed valid and reliable but not the gold standard) and subjects had been followed for the same length of time in all study groups OR it is deemed that the outcome assessment methods used would not appreciably bias results OR group-level outcomes were assessed using well-established methods. Acceptable, but not ideal assessment methods will depend on the outcome, but examples of such methods may include proxy reporting of outcomes and mining of data collected for other purposes.; Additional Guidance:; Death certificates are used, but there is no statement that they were coded by certified nosologist, OR information on the accuracy/validity/completeness of the death certificates is missing, OR incident cancer cases are not stated to be histologically confirmed, but the study was conducted in a hospital setting (e.g., hospital-based case-control study).
− | OHAT:; Human Controlled Trial, Cohort: There is indirect evidence that the outcome assessment method is an insensitive instrument, the authors did not validate the methods used, or the length of follow up differed by study group OR there is insufficient information provided about validation of outcome assessment method.; Case-Control: There is indirect evidence that the outcome was assessed in cases using an insensitive instrument or was not adequately validated OR there is insufficient information provided about how cases were identified.; Cross-sectional, Case Series/Report: There is indirect evidence that the outcome assessment method is an insensitive instrument or was not adequately validated OR there is insufficient information provided about validation of outcome assessment method.; Assessment-specific Clarification:; Ecological and Semi-individual: There is indirect evidence that the authors did not validate the methods used, or the length of follow up differed by study group OR there is insufficient information provided about validation of outcome assessment method.; Additional Guidance:; Outcome is self-reported (e.g., “ever been diagnosed by a physician”) and not verified by medical records or other means. There is insufficient information on quality of self-report or validation of answers. Outcome is assessed by nurses and there is no information on assessor agreement.
−− | OHAT:; Human Controlled Trial, Cohort: There is direct evidence that the outcome assessment method is an insensitive instrument, or the length of follow up differed by study group.; Case-Control: There is direct evidence that the outcome was assessed in cases using an insensitive instrument.; Cross-sectional, Case Series/Report: There is direct evidence that the outcome assessment method is an insensitive instrument.; Assessment-specific Clarification:; Ecological and Semi-individual: There is direct evidence that the authors did not validate the methods used, or the length of follow up differed by study group.; Additional Guidance:; Self-reported outcome when question is not worded “as diagnosed by a physician” and cannot be verified.
14. Were all measured outcomes reported?
++ | OHAT:; Human Controlled Trial, Cohort, Case-Control, Cross-sectional, Case Series/Report: There is direct evidence that all of the study’s measured outcomes (primary and secondary) outlined in the protocol, methods, abstract, and/or introduction (that are relevant for the evaluation) have been reported. This would include outcomes reported with sufficient detail to be included in meta-analysis or fully tabulated during data extraction.; Assessment-specific Clarification:; Ecological and Semi-individual: Same as OHAT criteria.; Additional Guidance:; None.
+ | OHAT:; Human Controlled Trial, Cohort, Case-Control, Cross-sectional, Case Series/Report: There is indirect evidence that all of the study’s measured outcomes (primary and secondary) outlined in the protocol, methods, abstract, and/or introduction (that are relevant for the evaluation) have been reported OR analyses that had not been planned at the outset of the study (i.e., retrospective unplanned subgroup analyses) are clearly indicated as such and it is deemed that the omitted analyses were not appropriate and selective reporting would not appreciably bias results. This would include outcomes reported with insufficient detail such as only reporting that results were statistically significant (or not).; Assessment-specific Clarification:; Ecological and Semi-individual: Same as OHAT criteria.; Additional Guidance:; All outcomes outlined in abstract, introduction, and methods are reported.
− | OHAT:; Human Controlled Trial, Cohort, Case-Control, Cross-sectional, Case Series/Report: There is indirect evidence that all of the study’s measured outcomes (primary and secondary) outlined in the protocol, methods, abstract, and/or introduction (that are relevant for the evaluation) have been reported OR there is insufficient information provided about selective outcome reporting.; Assessment-specific Clarification:; Ecological and Semi-individual: Same as OHAT criteria.; Additional Guidance:; An outcome mentioned in a part of the study report is obviously missing from the results.
−− | OHAT:; Human Controlled Trial, Cohort, Case-Control, Cross-sectional, Case Series/Report: There is direct evidence that all of the study’s measured outcomes (primary and secondary) outlined in the protocol, methods, abstract, and/or introduction (that are relevant for the evaluation) have not been reported. In addition to not reporting outcomes, this would include reporting outcomes based on composite score without individual outcome components or outcomes reported using measurements, analysis methods or subsets of the data (e.g., subscales) that were not pre-specified or reporting outcomes not pre-specified (unless clear justification for their reporting is provided, such as an unexpected effect).; Assessment-specific Clarification:; Ecological and Semi-individual: Same as OHAT criteria.; Additional Guidance:; None.
15. Were there no other potential threats to internal validity (e.g., statistical methods were appropriate)?
| OHAT: On a project specific basis, additional questions for other potential threats to internal validity can be added and applied to study designs as appropriate.
++ | Assessment-specific Clarification:; Statistical analyses were appropriate and no other threats to internal validity were identified. Study authors might acknowledge limitations, but these are not expected to affect the study’s internal validity.
+ | Assessment-specific Clarification:; There are study limitations likely to bias the results toward or away from the null, but adequate sample size was available in each cell (n ≥ 5), OR sample size is small and acknowledged as a potential limitation by study authors, but significant results were still observed.
− | Assessment-specific Clarification:; There are study limitations likely to bias results towards or away from the null, OR analyses were conducted on a small number of subjects (n < 5 in any given cell) and no statistically significant results were observed.
−− | Assessment-specific Clarification:; None.

## B.2 AUTHOR-PROVIDED DATA

As part of the screening (see assessment Section 4.2) and dose-response meta-analysis (see assessment Section 4.3) analyses study selection process, authors were contacted for additional data whenever the study met minimal requirements for inclusion in the analysis but not all data needed for the exposure-response analysis was available. The data supplied by the authors is documented in this Appendix section in Tables B-2 through B-16.

### B.2.1 Author-Provided Data for Screening Analyses

Table B-2 Data provided for Argos et al. (2007)

Study | Parameter | Cases | Non-cases | Notes
Argos et al. (2007) | Well water arsenic concentration (μg/L)
Skin Lesions (Owns Land) | <7 | 18 | 839 | Cases and non-cases provided by author
Hero ID: 627505 | 7–38 | 20 | 772 | Cases and non-cases provided by author
| 39–90 | 46 | 807 | Cases and non-cases provided by author
| 91–177 | 38 | 774 | Cases and non-cases provided by author
| >177 | 51 | 664 | Cases and non-cases provided by author
Argos et al. (2007) | Well water arsenic concentration (μg/L) | Cases | Non-cases | Notes
Skin Lesions (Does not own land) | <7 | 39 | 1,309 | Cases and non-cases provided by author
Hero ID: 627505 | 7–38 | 76 | 1,503 | Cases and non-cases provided by author
| 39–90 | 91 | 1,398 | Cases and non-cases provided by author
| 91–177 | 114 | 1,442 | Cases and non-cases provided by author
| >177 | 188 | 1,577 | Cases and non-cases provided by author
Argos et al. (2007) | Urinary As concentration (μg/g-creatinine) | Cases | Non-cases | Notes
Skin Lesions (Owns land) | ≤35 | 38 | 1,018 | Cases and non-cases provided by author
Hero ID: 627505 | 36–66 | 50 | 1,156 | Cases and non-cases provided by author
| 67–114 | 48 | 1,072 | Cases and non-cases provided by author
| 115–204 | 90 | 1,089 | Cases and non-cases provided by author
| >204 | 82 | 1,021 | Cases and non-cases provided by author
Argos et al. (2007) | Urinary As concentration (μg/g-creatinine) | Cases | Non-cases | Notes
Skin Lesions (Does not own land) | ≤35 | 36 | 1,101 | Cases and non-cases provided by author
Hero ID: 627505 | 36–66 | 49 | 1,050 | Cases and non-cases provided by author
| 67–114 | 70 | 1,079 | Cases and non-cases provided by author
| 115–204 | 78 | 1,039 | Cases and non-cases provided by author
| >204 | 125 | 1,149 | Cases and non-cases provided by author
Argos et al. (2007) | Cumulative As exposure (mg) | Cases | Non-cases | Notes
Skin Lesions (Owns land) | ≤62 | 34 | 1,208 | Cases and non-cases provided by author
Hero ID: 627505 | 62–224 | 37 | 933 | Cases and non-cases provided by author
| 225–583 | 54 | 1,096 | Cases and non-cases provided by author
| 584–1,490 | 74 | 1,023 | Cases and non-cases provided by author
| >1,490 | 110 | 1,049 | Cases and non-cases provided by author
Argos et al. (2007) | Cumulative As exposure (mg) | Cases | Non-cases | Notes
Skin Lesions (Does not own land) | ≤62 | 27 | 1,169 | Cases and non-cases provided by author
Hero ID: 627505 | 62–224 | 35 | 940 | Cases and non-cases provided by author
| 225–583 | 65 | 1,070 | Cases and non-cases provided by author
| 584–1,490 | 84 | 1,136 | Cases and non-cases provided by author
| >1,490 | 148 | 1,095 | Cases and non-cases provided by author

Table B-3 Data provided for Aschengrau et al. (1989)

Aschengrau et al. (1989) | Drinking water as exposure (μg/L) | Cases | Non-cases | Notes
Spontaneous abortion/miscarriage | Not detected | 128 | 701 | Cases and non-cases provided by author
Hero ID: 1032517 | 0.8–1.3 | 151 | 668 | Cases and non-cases provided by author
| 1.4–1.9 | 7 | 22 | Cases and non-cases provided by author

Table B-4 Data provided for Chen et al. (2011)

Chen et al. (2011) | Drinking water As concentration by mean (μg/L) | Total N | Notes
Hero ID: 1015960 | 3.7 | 2,982 | Total N per exposure level provided by author
| 35.9 | 2,943 | Total N per exposure level provided by author
| 102.5 | 2,886 | Total N per exposure level provided by author
| 265.7 | 2,935 | Total N per exposure level provided by author
Chen et al. (2011) | Urinary Arsenic Concentration by mean (μg/g creatinine) | Total N | Notes
Hero ID: 1015960 | 68.5 | 2,793 | Total N per exposure level provided by author
| 150.6 | 2,829 | Total N per exposure level provided by author
| 264.9 | 2,805 | Total N per exposure level provided by author
| 641.5 | 2,797 | Total N per exposure level provided by author

Table B-5 Data provided for D’Ippoliti et al. (2015)

D’Ippoliti et al. (2015) | Average As during first yr of residence (μg/L) | Total N | Notes
Males | <10 | 21,997 | Total N per exposure level provided by author
Hero ID: 3005297 | 10–20 | 20,533 | Total N per exposure level provided by author
| >20 | 26,228 | Total N per exposure level provided by author
D’Ippoliti et al. (2015) | Average As during first yr of residence (μg/L) | Total N | Notes
Females | <10 | 22,347 | Total N per exposure level provided by author
Hero ID: 3005297 | 10–20 | 20,946 | Total N per exposure level provided by author
| >20 | 26,749 | Total N per exposure level provided by author
D’Ippoliti et al. (2015) | Cumulative As Dose (mg) | Total N | Notes
Males | <204.9 | 26,944 | Total N per exposure level and unit provided by author
Hero ID: 3005297 | 204.9–804.0 | 44,537 | Total N per exposure level and unit provided by author
| >804 | 21,636 | Total N per exposure level and unit provided by author
D’Ippoliti et al. (2015) | Cumulative As Dose (mg) | Total N | Notes
Females | <204.9 | 26,459 | Total N per exposure level and unit provided by author
Hero ID: 3005297 | 204.9–804.0 | 44,702 | Total N per exposure level and unit provided by author
| >804 | 23,175 | Total N per exposure level and unit provided by author

Table B-6 Data provided for Gilbert-Diamond et al. (2013)

Gilbert-Diamond et al. (2013) | Total urinary arsenic (μg/L) | Cases | Controls | Notes
Hero ID: 1797805 | <3.36 | 165 | 141 | Cases and controls provided by author
| 3.36–<5.31 | 145 | 161 | Cases and controls provided by author
| ≥5.31 | 137 | 168 | Cases and controls provided by author
Gilbert-Diamond et al. (2013) | Inorganic urinary As (μg/L) | Cases | Controls | Notes
Hero ID: 1797805 | <0.23 | 156 | 153 | Cases and controls provided by author
| 0.23–<0.45 | 149 | 153 | Cases and controls provided by author
| ≥0.45 | 142 | 164 | Cases and controls provided by author

Table B-7 Data provided for James et al. (2015)

James et al. (2015) | As TWA exposure (μg/L-yr) | Mean As TWA exposure (μg/L-yr) | Cases | Non-cases | Notes
coronary heart disease | 1–20 | 7.31 | 58 | 370 | Means and cases provided by author and non-cases calculated against total n presented in paper
Hero ID: 2822189 | 20–30 | 25.1 | 18 | 68 | Means and cases provided by author and non-cases calculated against total n presented in paper
| 30–45 | 36.6 | 16 | 17 | Means and cases provided by author and non-cases calculated against total n presented in paper
| 45–88 | 50.2 | 4 | 4 | Means and cases provided by author and non-cases calculated against total n presented in paper

Table B-8 Data provided for Moon et al. (2013)

Moon et al. (2013) | Urinary As concentration (μg/g-creatinine) | Mean urinary As concentration (μg/g-creatinine) | Cases | Non-cases | Notes
coronary heart disease incidence | <5.8 | 4.10 | 202 | 694 | Means and non-cases provided by author
Hero ID: 2064267 | 5.8–9.7 | 7.60 | 206 | 687 | Means and non-cases provided by author
| 9.8–15.7 | 12.5 | 197 | 695 | Means and non-cases provided by author
| >15.7 | 26.3 | 241 | 653 | Means and non-cases provided by author
Moon et al. (2013) | Urinary As concentration (μg/g-creatinine) | Mean Urinary As concentration (μg/g-creatinine) | Cases | Non-cases | Notes
coronary heart disease mortality | <5.8 | 4.10 | 68 | 828 | Means and non-cases provided by author
Hero ID: 2064267 | 5.8–9.7 | 7.60 | 67 | 826 | Means and non-cases provided by author
| 9.8–15.7 | 12.5 | 87 | 805 | Means and non-cases provided by author
| >15.7 | 26.3 | 119 | 775 | Means and non-cases provided by author
Moon et al. (2013) | Urinary As concentration (μg/g-creatinine) | Mean Urinary As concentration (μg/g-creatinine) | Cases | Non-cases | Notes
cardiovascular disease incidence | <5.8 | 4.10 | 265 | 631 | Means and non-cases provided by author
Hero ID: 2064267 | 5.8–9.7 | 7.60 | 297 | 596 | Means and non-cases provided by author
| 9.8–15.7 | 12.5 | 291 | 601 | Means and non-cases provided by author
| >15.7 | 26.3 | 331 | 563 | Means and non-cases provided by author
Moon et al. (2013) | Urinary As concentration (μg/g-creatinine) | Mean Urinary As concentration (μg/g-creatinine) | Cases | Non-cases | Notes
cardiovascular disease mortality | <5.8 | 4.10 | 68 | 828 | Means and non-cases provided by author
Hero ID: 2064267 | 5.8–9.7 | 7.60 | 67 | 826 | Means and non-cases provided by author
| 9.8–15.7 | 12.5 | 87 | 805 | Means and non-cases provided by author
| >15.7 | 26.3 | 119 | 775 | Means and non-cases provided by author
Moon et al. (2013) | Urinary As concentration (μg/g-creatinine) | Mean Urinary As concentration (μg/g-creatinine) | Cases | Non-cases | Notes
stroke incidence | <5.8 | 4.10 | 55 | 841 | Means and non-cases provided by author
Hero ID: 2064267 | 5.8–9.7 | 7.60 | 75 | 818 | Means and non-cases provided by author
| 9.8–15.7 | 12.5 | 62 | 830 | Means and non-cases provided by author
| >15.7 | 26.3 | 72 | 822 | Means and non-cases provided by author
Moon et al. (2013) | Urinary As concentration (μg/g-creatinine) | Mean Urinary As concentration (μg/g-creatinine) | Cases | Non-cases | Notes
stroke mortality | <5.8 | 4.10 | 6 | 890 | Means and non-cases provided by author
Hero ID: 2064267 | 5.8–9.7 | 7.60 | 17 | 876 | Means and non-cases provided by author
| 9.8–15.7 | 12.5 | 13 | 879 | Means and non-cases provided by author
| >15.7 | 26.3 | 18 | 876 | Means and non-cases provided by author

Table B-9 Data provided for Sohel et al. (2009)

Sohel et al. (2009) | Average historic arsenic exposure (μg/L) | Mean historic arsenic exposure (μg/L) | Notes
Hero ID: 710822 | <10 | 1.40 | Means provided by author
| 10–49 | 31.1 | Means provided by author
| 50–149 | 97.0 | Means provided by author
| 150–299 | 209 | Means provided by author
| ≥300 | 403 | Means provided by author

Table B-10 Data provided for Tseng et al. (2003)

Tseng et al. (2003) | Total urinary arsenic (μg/L) | Cases | Non-cases | Notes
Hero ID: 628705 | 0 | 4 | 73 | Cases and non-cases provided by author
| 0.1–14.9 | 15 | 123 | Cases and non-cases provided by author
| ≥15 | 35 | 110 | Cases and non-cases provided by author

Table B-11 Data provided for Wade et al. (2009)

Wade et al. (2009) | Drinking water As concentration (μg/L) | Mean drinking water As concentration (μg/L) | Notes
Hero ID: 628466 | 0–5 | 1.61 | Means provided by author
| 5.1–20 | 12.0 | Means provided by author
| 20.1–100 | 38.9 | Means provided by author
| 100.1–300 | 168 | Means provided by author
| >300 | 421 | Means provided by author

Table B-12 Data provided for Wade et al. (2015)

Wade et al. (2015) | Water As concentration (μg/L) | Mean water As concentration (μg/L) | Notes
Hero ID: 2854656 | <10 | 3.02 | Means provided by author
| 10–39 | 20.9 | Means provided by author
| ≥40 | 78.8 | Means provided by author

Table B-13 Data provided for Wasserman et al. (2004)

Wasserman et al. (2004) | Drinking water As concentration (μg/L) | Total N | Full IQ score mean | SE | Notes
Hero ID: 180230 | 0.1–5.5 | 50 | 76.56 | 2.87 | Total N per exposure level and Full IQ score mean (SE) provided by author
| 5.6–50.0 | 50 | 71.81 | 2.89 | Total N per exposure level and Full IQ score mean (SE) provided by author
| 50.1–176 | 50 | 68.80 | 2.99 | Total N per exposure level and Full IQ score mean (SE) provided by author
| 177–790 | 51 | 65.25 | 2.89 | Total N per exposure level and Full IQ score mean (SE) provided by author
Wasserman et al. (2004) | Drinking water As concentration (μg/L) | Total N | Performance IQ score mean | SE | Notes
Hero ID: 180230 | 0.1–5.5 | 50 | 59.51 | 2.44 | Total N per exposure level and Performance IQ score mean (SE) provided by author
| 5.6–50.0 | 50 | 54.41 | 2.46 | Total N per exposure level and Performance IQ score mean (SE) provided by author
| 50.1–176 | 50 | 52.23 | 2.55 | Total N per exposure level and Performance IQ score mean (SE) provided by author
| 177–790 | 51 | 49.77 | 2.46 | Total N per exposure level and Performance IQ score mean (SE) provided by author
Wasserman et al. (2004) | Drinking water As concentration (μg/L) | Total N | Verbal IQ score mean | SE | Notes
Hero ID: 180230 | 0.1–5.5 | 50 | 17.05 | 0.74 | Total N per exposure level and Verbal IQ score mean (SE) provided by author
| 5.6–50.0 | 50 | 17.40 | 0.75 | Total N per exposure level and Verbal IQ score mean (SE) provided by author
| 50.1–176 | 50 | 16.56 | 0.78 | Total N per exposure level and Verbal IQ score mean (SE) provided by author
| 177–790 | 51 | 15.47 | 0.75 | Total N per exposure level and Verbal IQ score mean (SE) provided by author

Table B-14 Data provided for Wu et al. (2012)

Wu et al. (2012) | Well water As (μg/L) | MMP-9 mean (ng/mL) | SD | Notes
Hero ID: 1070384 | 0.10–2.00 | 105.90 | 59.30 | MMP-9 mean (SD) provided by author
| 2.01–23.13 | 101.20 | 78.70 | MMP-9 mean (SD) provided by author
| 23.14–73.46 | 104.10 | 62.20 | MMP-9 mean (SD) provided by author
| 73.47–500.62 | 107.00 | 70.10 | MMP-9 mean (SD) provided by author
Wu et al. (2012) | Well water As (μg/L) | MPO (ng/mL) | SD | Notes
Hero ID: 1070384 | 0.10–2.00 | 21.00 | 16.30 | MPO mean (SD) provided by author
| 2.01–23.13 | 20.30 | 14.10 | MPO mean (SD) provided by author
| 23.14–73.46 | 20.20 | 14.70 | MPO mean (SD) provided by author
| 73.47–500.62 | 20.30 | 14.00 | MPO mean (SD) provided by author
Wu et al. (2012) | Well water As (μg/L) | sE-selectin (ng/mL) | SD | Notes
Hero ID: 1070384 | 0.10–2.00 | 35.30 | 14.60 | sE-selectin mean (SD) provided by author
| 2.01–23.13 | 36.30 | 17.00 | sE-selectin mean (SD) provided by author
| 23.14–73.46 | 34.80 | 14.30 | sE-selectin mean (SD) provided by author
| 73.47–500.62 | 35.70 | 17.10 | sE-selectin mean (SD) provided by author
Wu et al. (2012) | Well water As (μg/L) | PAI-1 (ng/mL) | SD | Notes
Hero ID: 1070384 | 0.10–2.00 | 72.60 | 14.60 | PAI-1 mean (SD) provided by author
| 2.01–23.13 | 70.90 | 17.00 | PAI-1 mean (SD) provided by author
| 23.14–73.46 | 68.80 | 14.30 | PAI-1 mean (SD) provided by author
| 73.47–500.62 | 81.70 | 17.10 | PAI-1 mean (SD) provided by author
Wu et al. (2012) | Well water As (μg/L) | sICAM-1 (ng/mL) | SD | Notes
Hero ID: 1070384 | 0.10–2.00 | 160.70 | 145.00 | sICAM-1 mean (SD) provided by author
| 2.01–23.13 | 134.30 | 125.50 | sICAM-1 mean (SD) provided by author
| 23.14–73.46 | 136.00 | 94.60 | sICAM-1 mean (SD) provided by author
| 73.47–500.62 | 156.30 | 125.00 | sICAM-1 mean (SD) provided by author
Wu et al. (2012) | Well water As (μg/L) | sVCAM-1 (ng/mL) | SD | Notes
Hero ID: 1070384 | 0.10–2.00 | 1,001.70 | 325.10 | sVCAM-1 mean (SD) provided by author
| 2.01–23.13 | 1,054.70 | 331.20 | sVCAM-1 mean (SD) provided by author
| 23.14–73.46 | 1,109.50 | 312.40 | sVCAM-1 mean (SD) provided by author
| 73.47–500.62 | 1,117.90 | 344.10 | sVCAM-1 mean (SD) provided by author
Wu et al. (2012) | Urinary As (μg/g creatinine) | MMP-9 mean (ng/mL) | SD | Notes
Hero ID: 1070384 | 12.05–88.21 | 116.00 | 74.30 | MMP-9 mean (SD) provided by author
| 88.22–141.69 | 99.50 | 63.30 | MMP-9 mean (SD) provided by author
| 141.7–275.63 | 97.40 | 63.00 | MMP-9 mean (SD) provided by author
| 275.64–1,869.57 | 105.00 | 65.90 | MMP-9 mean (SD) provided by author
Wu et al. (2012) | Urinary As (μg/g creatinine) | MPO (ng/mL) | SD | Notes
Hero ID: 1070384 | 12.05–88.21 | 22.60 | 16.90 | MPO mean (SD) provided by author
| 88.22–141.69 | 18.90 | 12.10 | MPO mean (SD) provided by author
| 141.7–275.63 | 20.50 | 15.40 | MPO mean (SD) provided by author
| 275.64–1,869.57 | 19.80 | 14.10 | MPO mean (SD) provided by author
Wu et al. (2012) | Urinary As (μg/g creatinine) | sE-selectin (ng/mL) | SD | Notes
Hero ID: 1070384 | 12.05–88.21 | 37.40 | 16.30 | sE-selectin mean (SD) provided by author
| 88.22–141.69 | 35.00 | 15.10 | sE-selectin mean (SD) provided by author
| 141.7–275.63 | 33.70 | 14.60 | sE-selectin mean (SD) provided by author
| 275.64–1,869.57 | 35.50 | 16.40 | sE-selectin mean (SD) provided by author
Wu et al. (2012) | Urinary As (μg/g creatinine) | PAI-1 (ng/mL) | SD | Notes
Hero ID: 1070384 | 12.05–88.21 | 74.10 | 34.70 | PAI-1 mean (SD) provided by author
| 88.22–141.69 | 71.30 | 39.50 | PAI-1 mean (SD) provided by author
| 141.7–275.63 | 68.20 | 31.90 | PAI-1 mean (SD) provided by author
| 275.64–1,869.57 | 80.70 | 48.00 | PAI-1 mean (SD) provided by author
Wu et al. (2012) | Urinary As (μg/g creatinine) | sICAM-1 (ng/mL) | SD | Notes
Hero ID: 1070384 | 12.05–88.21 | 149.60 | 139.70 | sICAM-1 mean (SD) provided by author
| 88.22–141.69 | 142.20 | 114.50 | sICAM-1 mean (SD) provided by author
| 141.7–275.63 | 154.00 | 144.70 | sICAM-1 mean (SD) provided by author
| 275.64–1,869.57 | 147.20 | 92.30 | sICAM-1 mean (SD) provided by author
Wu et al. (2012) | Urinary As (μg/g creatinine) | sVCAM-1 (ng/mL) | SD | Notes
Hero ID: 1070384 | 12.05–88.21 | 1,010.90 | 320.90 | sVCAM-1 mean (SD) provided by author
| 88.22–141.69 | 1,053.50 | 345.90 | sVCAM-1 mean (SD) provided by author
| 141.7–275.63 | 1,120.80 | 331.60 | sVCAM-1 mean (SD) provided by author
| 275.64–1,869.57 | 1,126.60 | 314.70 | sVCAM-1 mean (SD) provided by author

Table B-15 Data provided for Stein et al. (2022)

parent_ test | subtest | pooled_beta | confidence_interval | p-value | LCI | UCI
NA | Verbal IQ | −1.017934754 | –2.63, 0.59 | 0.215171999 | –2.63 | 0.59
NA | Performance IQ | 0.48494538 | –1.09, 2.06 | 0.545407458 | –1.09 | 2.06
NA | Full Scale IQ | –0.734560552 | –2.32, 0.86 | 0.365099877 | –2.32 | 0.86
NEPSY | CI Score | –0.001605874 | –0.38, 0.37 | 0.993308141 | –0.38 | 0.37
NEPSY | DCP Total | 0.012601227 | –0.46, 0.48 | 0.958058487 | –0.46 | 0.48
NEPSY | Free and Cued Recall Score | 0.042054599 | –0.35, 0.43 | 0.833556118 | –0.35 | 0.43
NEPSY | Word Generation Semantic Score | –0.067636638 | –0.39, 0.26 | 0.682782765 | –0.39 | 0.26
WIAT | Numerical Operations Subtest Score | –0.690470411 | –2.52, 1.14 | 0.459979356 | –2.52 | 1.14
WIAT | Word / Pseudoword Average Score | –0.324756873 | –1.71, 1.06 | 0.64594691 | –1.71 | 1.06
CPTII | Clinical Confidence Index | –1.056682976 | –3.96, 1.85 | 0.475877101 | –3.96 | 1.85
CPTII | Omissions T-Score | –0.093380377 | –1.69, 1.5 | 0.9085007 | –1.69 | 1.5
CPTII | Comissions T-Score | 0.01881603 | −1.1, 1.14 | 0.973644447 | –1.1 | 1.14
CPTII | HitRT T-Score | –0.254002909 | –1.67, 1.16 | 0.724800328 | –1.67 | 1.16
Parent BRIEF | BRI T-Score | 0.867171261 | –0.52, 2.26 | 0.220965988 | –0.52 | 2.26
Parent BRIEF | MI T-Score | 0.953721822 | –0.51, 2.41 | 0.200282394 | –0.51 | 2.41
Parent BRIEF | GEC T-Score | 0.99223224 | –0.44, 2.42 | 0.174065981 | –0.44 | 2.42
Teacher BRIEF | BRI T-Score | 1.194008365 | –1.07, 3.46 | 0.301680795 | –1.07 | 3.46
Teacher BRIEF | MI T-Score | 0.344875246 | –2.13, 2.82 | 0.784981387 | –2.13 | 2.82
Teacher BRIEF | GEC T-Score | 0.693574201 | –1.72, 3.1 | 0.572623569 | –1.72 | 3.1
Parent CADS | ADHD T-Score | 1.137230024 | –0.4, 2.68 | 0.147406228 | –0.4 | 2.68
Parent CADS | Inattentive T-Score | 1.022174557 | –0.4, 2.44 | 0.158093595 | –0.4 | 2.44
Parent CADS | Hyperactive T-Score | 1.038023539 | –0.35, 2.43 | 0.143649586 | –0.35 | 2.43
Parent CADS | Total T-Score | 1.13895568 | –0.26, 2.53 | 0.109381903 | –0.26 | 2.53
Teacher CADS | ADHD T-Score | 0.158436285 | –1.86, 2.18 | 0.877744185 | –1.86 | 2.18
Teacher CADS | Inattentive T-Score | –0.085007167 | –1.66, 1.49 | 0.915579444 | –1.66 | 1.49
Teacher CADS | Hyperactive T-Score | 0.379928878 | –1.61, 2.37 | 0.707937338 | –1.61 | 2.37
Teacher CADS | Total T-Score | 0.002492712 | –1.98, 1.99 | 0.998037221 | –1.98 | 1.99
Parent BASC2 | Externalize T-Score | 0.688144098 | –0.54, 1.91 | 0.27048925 | –0.54 | 1.91
Parent BASC2 | Internalize T-Score | –0.24135664 | –1.74, 1.26 | 0.752498723 | –1.74 | 1.26
Parent BASC2 | Behavior T-Score | 0.444104383 | –0.86, 1.75 | 0.505390973 | –0.86 | 1.75
Parent BASC2 | Adaptability T-Score | –0.870227388 | –2.17, 0.43 | 0.188490827 | –2.17 | 0.43
Teacher BASC2 | Externalize T-Score | 0.109772118 | –1.44, 1.66 | 0.88983324 | –1.44 | 1.66
Teacher BASC2 | Internalize T-Score | –0.021848739 | –2.53, 2.49 | 0.986388133 | –2.53 | 2.49
Teacher BASC2 | Behavior T-Score | 0.216377529 | –1.76, 2.19 | 0.829689111 | –1.76 | 2.19
Teacher BASC2 | Adaptability T-Score | 0.181499655 | –2.12, 2.48 | 0.87701898 | –2.12 | 2.48

### B.2.2 Additional Author-Provided Data

The authors of Wasserman et al. (2004) and Wasserman et al. (2014) provided raw data for their studies which included individual data on exposures, outcomes, and covariates. The authors of Moon et al. (2017) provided data in supplemental materials that they had obtained from authors for the purposes of their meta-analysis. The author-provided data from these supplemental tables that were used in this assessment are summarized below in Table B-16.

Table B-16 Author-provided data obtained from Moon et al. (2017) meta-analysis

Data set (exposure units) | Exposure ranges | Means | Health outcome | Person years | Notes
Chen et al. (2011); (µg/g creatinine) | 6.6–105.9 | 68.5 | Fatal CVD | 18,818 | Means provided to Moon et al. (2017) by author
Chen et al. (2011); (µg/g creatinine) | 6.6–105.9 | 68.5 | Fatal IHD | 18,818 | Means provided to Moon et al. (2017) by author
Chen et al. (2011); (µg/g creatinine) | 105.9–199 | 150.6 | Fatal CVD | 18,335 | Means provided to Moon et al. (2017) by author
Chen et al. (2011); (µg/g creatinine) | 105.9–199 | 150.6 | Fatal IHD | 18,335 | Means provided to Moon et al. (2017) by author
Chen et al. (2011); (µg/g creatinine) | 199–351.8 | 264.9 | Fatal CVD | 18,161 | Means provided to Moon et al. (2017) by author
Chen et al. (2011); (µg/g creatinine) | 199–351.8 | 264.9 | Fatal IHD | 18,161 | Means provided to Moon et al. (2017) by author
Chen et al. (2011); (µg/g creatinine) | 351.8–1,100 | 641.5 | Fatal CVD | 18,501 | Means provided to Moon et al. (2017) by author
Chen et al. (2011); (µg/g creatinine) | 351.8–1,100 | 641.5 | Fatal IHD | 18,501 | Means provided to Moon et al. (2017) by author
Chen et al. (2013); (µg/L) | 0.1–25 | 7.20 | CVD Inc. | 2,823 | Means and person-yr provided to Moon et al. (2017) by author
Chen et al. (2013); (µg/L) | 0.1–25 | 7.20 | IHD Inc. | 2,823 | Means and person-yr provided to Moon et al. (2017) by author
Chen et al. (2013); (µg/L) | 25.1–107 | 59.90 | CVD Inc. | 2,718 | Means and person-yr provided to Moon et al. (2017) by author
Chen et al. (2013); (µg/L) | 25.1–107 | 59.90 | IHD Inc. | 2,718 | Means and person-yr provided to Moon et al. (2017) by author
Chen et al. (2013); (µg/L) | 108–864 | 222.80 | CVD Inc. | 2,770 | Means and person-yr provided to Moon et al. (2017) by author
Chen et al. (2013); (µg/L) | 108–864 | 222.80 | IHD Inc. | 2,770 | Means and person-yr provided to Moon et al. (2017) by author
D’Ippoliti et al. (2015); (µg/L) | 6.5 ± 2.8 | 6.5 ± 2.8 | Fatal CVD | 771,860 | Means and SDs and adjusted RRs for combined males and female responses were provided to Moon et al. (2017) by authors
D’Ippoliti et al. (2015); (µg/L) | 6.5 ± 2.8 | 6.5 ± 2.8 | Fatal IHD | 771,860 | Means and SDs and adjusted RRs for combined males and female responses were provided to Moon et al. (2017) by authors
D’Ippoliti et al. (2015); (µg/L) | 13.7 ± 2.6 | 13.7 ± 2. 6 | Fatal CVD | 713,276 | Means and SDs and adjusted RRs for combined males and female responses were provided to Moon et al. (2017) by authors
D’Ippoliti et al. (2015); (µg/L) | 13.7 ± 2.6 | 13.7 ± 2. 6 | Fatal IHD | 713,276 | Means and SDs and adjusted RRs for combined males and female responses were provided to Moon et al. (2017) by authors
D’Ippoliti et al. (2015); (µg/L) | 34.5 ± 19.7 | 34.5 ± 19.7 | Fatal CVD | 904,129 | Means and SDs and adjusted RRs for combined males and female responses were provided to Moon et al. (2017) by authors
D’Ippoliti et al. (2015); (µg/L) | 34.5 ± 19.7 | 34.5 ± 19.7 | Fatal IHD | 904,129 | Means and SDs and adjusted RRs for combined males and female responses were provided to Moon et al. (2017) by authors
James et al. (2015); (µg/L) | 1–20 | 7.31 | IHD Inc. | 4,806 | Means provided to Moon et al. (2017) by author
James et al. (2015); (µg/L) | 20–30 | 25.1 | IHD Inc. | 1,335 | Means provided to Moon et al. (2017) by author
James et al. (2015); (µg/L) | 30–45 | 36.6 | IHD Inc. | 534 | Means provided to Moon et al. (2017) by author
James et al. (2015); (µg/L) | 45–88 | 50.2 | IHD Inc. | 98 | Means provided to Moon et al. (2017) by author
Moon et al. (2013) (µg/g creatinine); 12,146–for CVD and IHD incidence; 13,616–for CVD and IHD fatality | 0–5.8 | 4.1 | CVD Inc. | 12,146 | Means and person-yr provided to Moon et al. (2017) by author
Moon et al. (2013) (µg/g creatinine); 12,146–for CVD and IHD incidence; 13,616–for CVD and IHD fatality | 0–5.8 | 4.1 | IHD Inc. | 12,146 | Means and person-yr provided to Moon et al. (2017) by author
Moon et al. (2013) (µg/g creatinine); 12,146–for CVD and IHD incidence; 13,616–for CVD and IHD fatality | 0–5.8 | 4.1 | Fatal CVD | 13,616 | Means and person-yr provided to Moon et al. (2017) by author
Moon et al. (2013) (µg/g creatinine); 12,146–for CVD and IHD incidence; 13,616–for CVD and IHD fatality | 0–5.8 | 4.1 | Fatal IHD | 13,616 | Means and person-yr provided to Moon et al. (2017) by author
Moon et al. (2013) (µg/g creatinine); 12,146–for CVD and IHD incidence; 13,616–for CVD and IHD fatality | 5.8–9.7 | 7.6 | CVD Inc. | 11,701 | Means and person-yr provided to Moon et al. (2017) by author
Moon et al. (2013) (µg/g creatinine); 12,146–for CVD and IHD incidence; 13,616–for CVD and IHD fatality | 5.8–9.7 | 7.6 | IHD Inc. | 11,701 | Means and person-yr provided to Moon et al. (2017) by author
Moon et al. (2013) (µg/g creatinine); 12,146–for CVD and IHD incidence; 13,616–for CVD and IHD fatality | 5.8–9.7 | 7.6 | Fatal CVD | 13,430 | Means and person-yr provided to Moon et al. (2017) by author
Moon et al. (2013) (µg/g creatinine); 12,146–for CVD and IHD incidence; 13,616–for CVD and IHD fatality | 5.8–9.7 | 7.6 | Fatal IHD | 13,430 | Means and person-yr provided to Moon et al. (2017) by author
Moon et al. (2013) (µg/g creatinine); 12,146–for CVD and IHD incidence; 13,616–for CVD and IHD fatality | 9.7–15.7 | 12.5 | CVD Inc. | 11,305 | Means and person-yr provided to Moon et al. (2017) by author
Moon et al. (2013) (µg/g creatinine); 12,146–for CVD and IHD incidence; 13,616–for CVD and IHD fatality | 9.7–15.7 | 12.5 | IHD Inc. | 11,305 | Means and person-yr provided to Moon et al. (2017) by author
Moon et al. (2013) (µg/g creatinine); 12,146–for CVD and IHD incidence; 13,616–for CVD and IHD fatality | 9.7–15.7 | 12.5 | Fatal CVD | 12,720 | Means and person-yr provided to Moon et al. (2017) by author
Moon et al. (2013) (µg/g creatinine); 12,146–for CVD and IHD incidence; 13,616–for CVD and IHD fatality | 9.7–15.7 | 12.5 | Fatal IHD | 12,720 | Means and person-yr provided to Moon et al. (2017) by author
Moon et al. (2013) (µg/g creatinine); 12,146–for CVD and IHD incidence; 13,616–for CVD and IHD fatality | >15.7 | 26.3 | CVD Inc. | 10,586 | Means and person-yr provided to Moon et al. (2017) by author
Moon et al. (2013) (µg/g creatinine); 12,146–for CVD and IHD incidence; 13,616–for CVD and IHD fatality | >15.7 | 26.3 | IHD Inc. | 10,586 | Means and person-yr provided to Moon et al. (2017) by author
Moon et al. (2013) (µg/g creatinine); 12,146–for CVD and IHD incidence; 13,616–for CVD and IHD fatality | >15.7 | 26.3 | Fatal CVD | 12,033 | Means and person-yr provided to Moon et al. (2017) by author
Moon et al. (2013) (µg/g creatinine); 12,146–for CVD and IHD incidence; 13,616–for CVD and IHD fatality | >15.7 | 26.3 | Fatal IHD | 12,033 | Means and person-yr provided to Moon et al. (2017) by author
Sohel et al. (2009) (µg/d) | 0–10 | 1.40 | Fatal CVD | 114,068 | Person-yr and means provided to Moon et al. (2017) by author
Sohel et al. (2009) (µg/d) | 10–49 | 31.06 | Fatal CVD | 139,233 | Person-yr and means provided to Moon et al. (2017) by author
Sohel et al. (2009) (µg/d) | 50–149 | 97.04 | Fatal CVD | 365,496 | Person-yr and means provided to Moon et al. (2017) by author
Sohel et al. (2009) (µg/d) | 150–299 | 208.61 | Fatal CVD | 241,930 | Person-yr and means provided to Moon et al. (2017) by author
Sohel et al. (2009) (µg/d) | 300–500 | 402.55 | Fatal CVD | 78,786 | Person-yr and means provided to Moon et al. (2017) by author
Wade et al. (2009) (µg/L) | 0–5 | 1.61 | Fatal CVD | 14,636 | Person-yr and means provided to Moon et al. (2017) by author
Wade et al. (2009) (µg/L) | 0–5 | 1.61 | Fatal IHD | 14,636 | Person-yr and means provided to Moon et al. (2017) by author
Wade et al. (2009) (µg/L) | 5–20 | 11.98 | Fatal CVD | 9,047 | Person-yr and means provided to Moon et al. (2017) by author
Wade et al. (2009) (µg/L) | 5–20 | 11.98 | Fatal IHD | 9,047 | Person-yr and means provided to Moon et al. (2017) by author
Wade et al. (2009) (µg/L) | 20–100 | 38.86 | Fatal CVD | 21,367 | Person-yr and means provided to Moon et al. (2017) by author
Wade et al. (2009) (µg/L) | 20–100 | 38.86 | Fatal IHD | 21,367 | Person-yr and means provided to Moon et al. (2017) by author
Wade et al. (2009) (µg/L) | 100–300 | 168.22 | Fatal CVD | 3,313 | Person-yr and means provided to Moon et al. (2017) by author
Wade et al. (2009) (µg/L) | 100–300 | 168.22 | Fatal IHD | 3,313 | Person-yr and means provided to Moon et al. (2017) by author
Wade et al. (2009) (µg/L) | 300–500 | 421.18 | Fatal CVD | 249 | Person-yr and means provided to Moon et al. (2017) by author
Wade et al. (2009) (µg/L) | 300–500 | 421.18 | Fatal IHD | 249 | Person-yr and means provided to Moon et al. (2017) by author
Wade et al. (2015) (µg/L); Case-control | 0–10 | 3.02 | IHD Inc. | – | Means provided to Moon et al. (2017) by author
Wade et al. (2015) (µg/L); Case-control | 10–39 | 20.87 | IHD Inc. | – | Means provided to Moon et al. (2017) by author
Wade et al. (2015) (µg/L); Case-control | 40–208 | 78.75 | IHD Inc. | – | Means provided to Moon et al. (2017) by author

## B.3 2022 LITERATURE SEARCH UPDATE AND SURVEY OF DCS AND DIABETES

Literature searches and updates were completed between 2012 and 2019. Following prioritization of the 6 select outcomes, another literature search was conducted in 2022 (see Figure B-1). A screening and survey of the newly identified studies was conducted to determine if the new studies on DCS and diabetes will impact conclusions in the draft assessment. To further screen studies for dose-response utility, additional consideration was given to study type and key confounding factors, such as smoking, that are important to the dose-response approach. Sixty-seven DCS and diabetes studies were identified, and a literature survey was conducted based on title/abstract screening (see Table B-17). The characterization of newly identified studies focused on EPA’s judgment of whether the studies would have a material impact on the conclusions (i.e., identified hazards or toxicity values) in the external review draft. [Note: For pregnancy and birth outcomes and neurodevelopmental effects, studies identified in the 2022 update underwent risk of bias evaluation to determine if new studies would change the hazard conclusion and/or impact dose-response analyses. Studies from the recent literature search update are included in the synthesis sections for pregnancy and birth outcomes and neurodevelopmental effects.]

Figure B-1 Literature search and screening flow diagram for inorganic arsenic (August 2022 search update)

^1^ Studies may be in multiple groups.

Table B-17 Literature survey of DCS and diabetes studies identified from 2022 literature search update

Reference (HERO ID) | Health outcome | Summary of study findings | EPA characterization for hazard identification | Included in dose-response meta-analysis (rationale)
Bulka et al. (2019) | DCS, Diabetes | Association observed for urinary iAs/Hg pattern due to elevated prevalence of high blood pressure, low HDL, and high triglycerides among those with greater exposures | Based on title/abstract screening for newly identified studies identified in the most recent literature search update, EPA has determined that these new studies will not have a material impact on the hazard conclusions for DCS and diabetes in the external review draft. | No (cross-sectional study)
Kupsco et al. (2019) | DCS | Blood arsenic associated with lower leptin in children 4–6 yo | | No (blood biomarker study)
Wen et al. (2019) | DCS | Plasma arsenic associated with increased risk of ischemic stroke | | No (blood biomarker study)
Wang et al. (2020a) | DCS | Study investigated association between metals in blood and hypertension; arsenic measured but not mentioned in results | | No (cross-sectional study)
Medina-Estevez et al. (2020) | DCS | Study investigated association between metals in blood and stroke; arsenic not mentioned in results | | No (blood biomarker study)
Zhong et al. (2019) | DCS | Urinary arsenic associated with increased incidence of hypertension | | No (hypertension study)
Wang et al. (2020e) | DCS | Blood arsenic associated with increased prevalence of preeclampsia | | No (blood biomarker study)
Howe et al. (2021) | DCS | Child blood pressure study, urinary arsenic measured but not mentioned in results | | No (did not adjust for creatinine)
Velmurugan et al. (2020) | DCS, Diabetes | Total organophosphate level and arsenic accumulation in serum showed association with diabetes and atherosclerosis | | No (cross-sectional study)
Karakulak et al. (2021) | DCS | Blood arsenic associated with diastolic dysfunction | | No (cross-sectional study)
Torres-Arellano et al. (2020) | DCS | Associations between plasma BNP and urinary arsenic exposure | | No (cross-sectional study)
Sobel et al. (2020) | DCS | Rice intake and urinary arsenic was not associated with subclinical CVD markers in a multiethnic US population | | No (rice intake study)
Xu et al. (2020) | DCS | CVD risks increased with iAs exposure from rice at exposures above 0.3 μg/person/day | | No (ecological study)
Suchy-Dicey et al. (2020) | DCS | Significant associations between urinary arsenic and higher burden of white matter hyperintensity (WMH) | | No (not a dose-response meta-analysis endpoint–vascular brain injury or cerebral atrophy)
Pichler et al. (2019) | DCS | Urinary arsenic associated with an increase in LV wall thickness and LV hypertrophy in young American Indians | | No (not a dose-response meta-analysis endpoint–cardiac geometry and left ventricular function)
Karakis et al. (2021) | DCS, Pregnancy, Neuro | Behavioral outcomes associated with urinary arsenic in children | | No (did not adjust for creatinine)
Scannell Bryan et al. (2019) | DCS | Urinary arsenic associated with high blood pressure | | No (blood pressure study)
Al-Forkan et al. (2021) | DCS | Urinary arsenic associated with SNPs | | No (cross-sectional study)
Kaufman et al. (2021) | DCS | Association of urinary arsenic exposure biomarkers with blood pressure, and possible non-linear effects on incident hypertension | | No (cros-ssectional study)
Xu and Polya (2021) | DCS | Association of arsenic in rice and hypertension | | No (cross-sectional study)
Ghaedrahmat et al. (2021) | DCS, Diabetes | Association of urinary arsenic and high fasting blood sugars | | No (not a dose-response meta-analysis endpoint–metabolic syndrome)
Zhang et al. (2022c) | DCS | No difference in arsenic serum between hypertensive and control groups | | No (cross-sectional study)
Nigra et al. (2021) | DCS | Urinary iAs exposure at low-to moderate-levels is consistent with increased heart disease mortality | | No (not a dose-response meta-analysis endpoint–mortality from heart disease [all diseases of the heart])
Grau-Perez et al. (2022) | DCS | Urinary arsenic associated with atherosclerosis risk factors | | No (cross-sectional study)
Xu et al. (2022) | DCS | Urinary arsenic associated with diabetes | | No (cross-sectional study)
Skalny et al. (2021) | DCS | Hair arsenic associated with IHD in normal weight and obese | | No (hair biomarker study)
Wang et al. (2021b) | DCS | Urinary arsenic exposure associated with changes in blood pressure during pregnancy | | No (not a dose-response meta-analysis endpoint–blood pressure)
Yen et al. (2022) | DCS | Study looked at metals and stroke; arsenic in serum and urine measured but not discussed in results | | No (cross-sectional study)
Nasab et al. (2022) | DCS, Diabetes | Urinary arsenic associated with FBS and lipid profile (TC, TG, LDL, HDL) | | No (cross-sectional study)
Wang et al. (2021a) | DCS | Urinary arsenic associated with changes in blood pressure in midlife women | | No (not a dose-response meta-analysis endpoint–blood pressure)
Zhang et al. (2022a) | DCS | Arsenic in blood measured in hypertension study but not mentioned in results | | No (cross-sectional study)
Andrews et al. (2022) | DCS | Arsenic exposures during pregnancy were consistently associated with increased average maternal systolic and diastolic BP. | | No (not a dose-response meta-analysis endpoint–blood pressure)
Cheng et al. (2021) | DCS | ADIPOQ/rs266729 and FABP2/rs1799883 polymorphisms affect susceptibility to essential hypertension in individuals exposed to high levels of arsenic | | No (not a dose-response meta-analysis endpoint - hypertension)
da Silva Nunes et al. (2022) | DCS, Diabetes | Negative association between urinary arsenic and VAI, triglycerides, and VLDL cholesterol; Urinary arsenic negatively associated with systolic blood pressure | | No (cross-sectional study)
Tang et al. (2022) | DCS | Urinary As associated with diastolic blood pressure in non-Hispanic Asians; urinary As associated with increased systolic BP in other groups | | No (cross-sectional study)
Liu et al. (2022c) | DCS | Null association between urinary As and coronary heart disease | | No (ORs not reported by dose group)
Liu et al. (2022a) | DCS | Blood arsenic associated with preeclampsia | | No (cross-sectional study)
Farzan et al. (2022) | DCS | Well water As concentrations associated with endothelial dysfunction as measured by reactive hyperemia index | | No (cross-sectional study)
Xua et al. (2021) | DCS | Conflicting associations between drinking water As concentrations and hypertension, and low and high density lipoprotein | | No (cross-sectional study)
Liu et al. (2022b) | DCS | Generally null associations between urinary As and measures of hypertension in children | | No (not a study type applicable to dose-response meta-analysis)
Kuo et al. (2022) | DCS | Urinary As associated with increased cardiovascular mortality | | No (numeric dose groups not reported)
Paul et al. (2019) | Diabetes | As drinking water concentration associated with prevalence of hyperglycemia, impaired glucose tolerance, and diabetes | | No (cross-sectional study)
Eick et al. (2019) | Diabetes | As drinking water exposure associated with increased risk of diabetes in low SES, but not high SES, populations | | No (high exposure population)
Wang et al. (2020b) | Diabetes | Urinary As levels associated with increased risk of gestational diabetes | | No (gestational diabetes study)
Saba et al. (2020) | Diabetes | Urinary As associated with non-statistically significant increase in diabetes | | No (did not adjust for creatinine)
Hendryx et al. (2019) | Diabetes | As from air and water emissions statistically significantly associated with increased risk of diabetes | | No (not a drinking water study)
Rehman et al. (2019) | Diabetes | Urinary As concentration associated with random blood glucose and HBA1c | | No (iAs risk values not reported)
Wang et al. (2020c) | Diabetes | Blood As concentration statistically significantly associated with diabetes | | No (numeric dose groups not reported)
Wang et al. (2020d) | Diabetes | Urinary As concentration associated with slightly faster rate of HOMA-beta decline (homeostatic model assessment of insulin resistance) | | No (numeric dose groups not reported)
Wang et al. (2019) | Diabetes | Blood As associated with increased risk of gestational diabetes | | No (gestational diabetes study)
Dai et al. (2020) | Diabetes | Blood As (exposure from coal burning) associated with significantly increased risk of diabetes | | No (blood biomarker study)
Zhang et al. (2020) | Diabetes | Urinary DMA levels associated with increased risk of diabetes | | No (cross-sectional study)
Arab YarMohammadi et al. (2021) | Diabetes | Cases of type 2 diabetes had four times higher urinary As levels compared to controls | | No (cross-sectional study)
Lucio et al. (2020) | Diabetes | Urinary total As and As metabolites positively correlated with hemoglobin A1c | | No (iAs risk values not reported)
Yang et al. (2019) | Diabetes | Null association between toenail As and diabetes, fasting glucose, insulin, or homeostatic model assessment of insulin resistance | | No (toenail biomarker study)
Tinkelman et al. (2020) | Diabetes | Urinary maternal As associated with increased diabetes | | No (numeric dose groups not reported)
Chen et al. (2021) | Diabetes | Null association between urinary As and gestational diabetes, however women with gestational diabetes has impaired methylation capacity | | No, gestational diabetes study
Zhang et al. (2022b) | Diabetes | Null association between blood and urinary As and diabetes and fasting glucose | | No (cross-sectional study)
Jia et al. (2021) | Diabetes | Null association between maternal hair As and gestational diabetes | | No (hair biomarker study, gestational diabetes study)
Weiss et al. (2022) | Diabetes | Urinary As associated with lower HOMA-beta and HOMA-IR and lower HOMA-S | | No (cross-sectional study)
Wang et al. (2022) | Diabetes | Urinary As provided positive weight to environmental risk score for metabolic syndrome | | No (gestational diabetes study)
Wu et al. (2021) | Diabetes | Null association between total urinary As and prediabetes, diabetes, or HbA1c | | No (numeric dose groups not reported)
Rangel-Moreno et al. (2022) | Diabetes | Positive association with urinary arsenic and diabetes | | No (non-monotonic dose response)
Fan et al. (2022) | Diabetes | Increased risk of diabetes with increasing urinary As concentration | | No (numeric dose groups not reported)
Zhou et al. (2022) | Diabetes | Evidence of increased insulin resistance with increasing urinary As concentration | | No (cross-sectional study)
Yang et al. (2022) | Diabetes | Null association with As and risk of diabetes | | No (cross-sectional study)
Li et al. (2021) | Diabetes | Rice consumption associated with lower urinary MMA and increased insulin resistance, especially in obese individuals | | No (cross-sectional study)

## B.4 HEAT MAPS OF LOW AND UNIFORMATIVE STUDIES

Figure B-2 Study evaluation ratings for low and uninformative references evaluating diseases of the circulatory system (DCS) (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/DCS-Low-Uninformative/))

Figure B-3 Study evaluation ratings for low confidence references evaluating diabetes (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Diabetes-Low-Confidence/))

Figure B-4 Study evaluation ratings for low and uninformative references evaluating fetal, newborn, and infant health outcomes (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Pregnancy-Low-Uniformative/))

Figure B-5 Study evaluation ratings for low and uninformative references evaluating neurodevelopmental effects (see interactive version in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500243/Neuro-Low-Uninformative/))

## B.5 DATA PIVOTS FOR EXPOSURES TO INORGANIC ARSENIC IN DRINKING WATER AT CONCENTRATIONS LESS THAN OR EQUAL TO 100 µG/L

### B.5.1 Diseases of the circulatory system

Figure B-6 Thumbnail schematic of case-control, nested case-control, and cross-sectional studies of atherosclerosis in response to inorganic arsenic exposure less than or equal to 100 µg/L, ratio measures, drinking water, categorical exposure (see interactive data graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Low-exposure-Atherosclerosis-case-controlcoho-4160/))

Figure B-7 Thumbnail schematic of cross-sectional studies of cerebrovascular disease and stroke in response to inorganic arsenic exposure less than or equal to 100 µg/L, ratio measures, drinking water, categorical exposure (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Low-exposure-Cerebrovascular-cross-sectional-4264/))

Figure B-8 Thumbnail schematic of case-control and cohort studies of stroke mortality and stroke in response to inorganic arsenic exposure less than or equal to 100 µg/L, biomarkers, drinking water, categorical exposure (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Low-exposure-Cerebrovascular-ratio-measures-c-8db0/))

Figure B-9 Thumbnail schematic of case-control and cohort studies of stroke mortality and cerebrovascular disease mortality in response to inorganic arsenic exposure less than or equal to 100 µg/L, ratio measures, drinking water, categorical exposure (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Low-exposure-Cerebrovascular-ratio-measures-c-9d2a/))

Figure B-10 Thumbnail schematic of case-control and cohort studies of CVD and CVD mortality in response to inorganic arsenic exposure less than or equal to 100 µg/L, ratio measures, biomarker, categorical exposure (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Low-exposure-DCS-CVD-case-controlcohort-ratio-e3f2/))

Figure B-11 Thumbnail schematic of case-control and cohort studies of CVD and CVD mortality in response to inorganic arsenic exposure less than or equal to 100 µg/L, ratio measures, drinking water, categorical exposure (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Low-exposure-DCS-CVD-case-controlcohort-ratio-7baf/))

Figure B-12 Thumbnail schematic of cross-sectional studies of hypertension in response to inorganic arsenic exposure less than or equal to 100 µg/L, ratio measures, drinking water, categorical exposure (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Low-exposure-Hypertension-cross-sectional-rat-5ae3/))

Figure B-13 Thumbnail schematic of case-control and cohort studies of IHD and IHD mortality in response to inorganic arsenic exposure less than or equal to 100 µg/L, ratio measures, biomarkers, categorical exposure (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Low-exposure-DCS-IHD-case-controlcohort-ratio-4fa0/))

Figure B-14 Thumbnail schematic of case-control and cohort studies of IHD and IHD mortality in response to inorganic arsenic exposure less than or equal to 100 µg/L, ratio measures, drinking water, categorical exposure (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Low-exposure-DCS-IHD-case-controlcohort-ratio-b0af/))

### B.5.2 Diabetes

Figure B-15 Thumbnail schematic of case-control and cohort studies of diabetes in response to inorganic arsenic exposure less than or equal to 100 µg/L, ratio measures, urine, categorical exposure (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Low-exposure-Diabetes-case-controlcohort-rati-b37d/))

Figure B-16 Thumbnail schematic of case-control and cohort studies of diabetes in response to inorganic arsenic exposure less than or equal to 100 µg/L, ratio measures, drinking water, categorical exposure (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Low-exposure-Diabetes-Case-controlCohort-rati-5310/))

Figure B-17 Thumbnail schematic of cross-sectional studies of diabetes in response to inorganic arsenic exposure less than or equal to 100 µg/L, ratio measures, drinking water, categorical exposure (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Low-exposure-Diabetes-cross-sectional-ratio-m-b503/))

### B.5.3 Fetal, newborn, and infant health outcomes

Figure B-18 Thumbnail schematic of cohort studies of birth length in response to inorganic arsenic exposure less than or equal to 100 µg/L, difference measures, biomarkers, categorical exposure (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Supplemental-birth-length-difference-measures-7975/))

Figure B-19 Thumbnail schematic of cohort studies of birth weight in response to inorganic arsenic exposure less than or equal to 100 µg/L, difference measures, biomarkers, continuous exposure (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Supplemental-Birth-Weight-difference-measure-f19e/))

Figure B-20 Thumbnail schematic of cohort studies of birth weight in response to inorganic arsenic exposure less than or equal to 100 µg/L, difference measures, drinking water, categorical exposures (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Supplemental-Birth-Weight-difference-measures-0cd5/))

Figure B-21 Thumbnail schematic of cohort studies of gestational age in response to inorganic arsenic exposure less than or equal to 100 µg/L, difference measures, biomarkers, categorical exposures (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Supplemental-Gestational-Age-difference-measu-4038/))

Figure B-22 Thumbnail schematic of cohort studies of gestational age in response to inorganic arsenic exposure less than or equal to 100 µg/L, difference measures, biomarkers, continuous exposures (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Supplemental-Gestational-Age-difference-measu-5f44/))

Figure B-23 Thumbnail schematic of cohort studies of head growth in response to inorganic arsenic exposure less than or equal to 100 µg/L, difference measures, biomarkers, categorical exposures (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Supplemental-Head-growth-difference-measures-ed86/))

Figure B-24 Thumbnail schematic of cohort studies of head growth in response to inorganic arsenic exposure less than or equal to 100 µg/L, difference measures, biomarkers, continuous exposures (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Supplemental-Head-growth-difference-measures-6037/))

Figure B-25 Thumbnail schematic of cross-sectional and ecological studies of infant/neonatal death in response to inorganic arsenic exposure less than or equal to 100 µg/L, ratio measures, drinking water, categorical exposures (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Supplemental-infantneonatal-death-ratio-measu-6ab8/))

Figure B-26 Thumbnail schematic of cohort studies of measures of length in response to inorganic arsenic exposure less than or equal to 100 µg/L, difference measures, biomarkers, continuous exposures (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Supplemental-Measures-of-length-difference-me-9b88/))

Figure B-27 Thumbnail schematic of cohort studies of prematurity in response to inorganic arsenic exposure less than or equal to 100 µg/L, ratio measures, drinking water, continuous exposure (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Supplemental-Prematurity-ratio-measures-water-aab9/))

Figure B-28 Thumbnail schematic of cohort studies of stillbirth, fetal loss, and spontaneous abortion in response to inorganic arsenic exposure less than or equal to 100 µg/L, ratio measures, biomarkers, categorical exposures (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Supplemental-Stillbirth-Fetal-Loss-and-Sponta-046c/))

Figure B-29 Thumbnail schematic of cohort studies of stillbirth, fetal loss, and spontaneous abortion in response to inorganic arsenic exposure less than or equal to 100 µg/L, ratio measures, drinking water, categorical exposures (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Supplemental-Stillbirth-Fetal-Loss-and-Sponta-e6ba/))

### B.5.4 Neurodevelopmental effects

Figure B-30 Thumbnail schematic of cross-sectional studies of developmental neurocognitive effects in response to inorganic arsenic exposure less than or equal to 100 µg/L, difference measures, drinking water, categorical exposures (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Supplemental-developmental-neurocognitive-cro-160b/))

Figure B-31 Thumbnail schematic of cross-sectional studies of developmental neurocognitive effects in response to inorganic arsenic exposure less than or equal to 100 µg/L, difference measures, nonblood biomarkers, continuous exposures (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Supplemental-developmental-neurocognitive-cro-55b1/))

Figure B-32 Thumbnail schematic of cross-sectional studies of developmental neurocognitive effects in response to inorganic arsenic exposure less than or equal to 100 µg/L, ratio measures, biomarkers, continuous exposures (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Supplemental-developmental-neurocognitive-cro-b351/))

Figure B-33 Thumbnail schematic of cohort studies of developmental neurocognitive effects in response to inorganic arsenic exposure less than or equal to 100 µg/L, difference measures, biomarkers, categorical exposures (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Supplemental-developmental-neurocognitive-coh-ecbb/))

Figure B-34 Thumbnail schematic of cohort studies of developmental neurocognitive effects in response to inorganic arsenic exposure less than or equal to 100 µg/L, difference measures, urine, continuous exposures (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Supplemental-developmental-neurocognitive-coh-c2d0/))

Figure B-35 Thumbnail schematic of cohort and cross-sectional studies of motor effects in response to inorganic arsenic exposure less than or equal to 100 µg/L, difference measures, biomarkers, continuous exposures (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Supplemental-motor-effects-difference-measure-b634/))

Figure B-36 Thumbnail schematic of a cross-sectional study of social, behavioral, emotional effects in response to inorganic arsenic exposure less than or equal to 100 µg/L, difference measures, biomarkers, continuous exposures (see interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500243/Supplemental-social-behav-emotional-differenc-2313/))