# APPENDIX A SYSTEMATIC REVIEW PROTOCOL FOR THE IRIS INORGANIC ARSENIC ASSESSMENT

In May 2019, the IRIS Program released an Updated Problem Formulation and Systematic Review Protocol for the IRIS Inorganic Arsenic Assessment for a 30-day public comment period. The updated protocol was then discussed with the National Academies of Sciences, Engineering, and Medicine (NASEM) at a public meeting on July 16, 2019. Following this public release, the systematic review protocol was updated taking NASEM recommendations and public comments into consideration, and can be found on the IRIS website at the following location (see the Downloads section: https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=343951#tab-3).