# ABBREVIATIONS

ACGIH: American Conference of Governmental Industrial Hygienists
AIC: Akaike’s information criterion
ALD: approximate lethal dosage
ALT: alanine aminotransferase
AST: aspartate aminotransferase
atm: atmosphere
ATSDR: Agency for Toxic Substances and Disease Registry
BMD: benchmark dose
BMDL: benchmark dose lower confidence limit
BMDU: benchmark dose upper confidence limit
BML: benchmark concentration lower confidence limit
BMCU: benchmark concentration upper confidence limit
BMDS: Benchmark Dose Software
BMR: benchmark response
BUN: blood urea nitrogen
BW: body weight
CA: chromosomal aberration
CASRN: Chemical Abstracts Service Registry Number
CBI: covalent binding index
CHO: Chinese hamster ovary (cell line)
CL: confidence limit
CNS: central nervous system
CPN: chronic progressive nephropathy
CYP450: cytochrome P450
DAF: dosimetric adjustment factor
DCS: diseases of the circulatory system
DEN: diethylnitrosamine
DMSO: dimethylsulfoxide
DMA: dimethylarsinic acid
DNA: deoxyribonucleic acid
EPA: Environmental Protection Agency
FDA: Food and Drug Administration
FEV_1_: forced expiratory volume of 1 second
GD: gestation day
GDH: glutamate dehydrogenase
GGT: γ-glutamyl transferase
GSH: glutathione
GST: glutathione-S-transferase
HAWC: Health Assessment Workspace Collaborative
Hb/g-A: animal blood: gas partition coefficient
Hb/g-H: human blood: gas partition coefficient
HEC: human equivalent concentration
HED: human equivalent dose
HERO: Health and Environmental Research Online
IARC: International Agency for Research on Cancer
iAs: inorganic arsenic
i.p.: intraperitoneal
IPCS: International Program on Chemical Safety
IRIS: Integrated Risk Information System
IVF: in vitro fertilization
LC_50_: median lethal concentration
LD_50_: median lethal dose
LOAEL: lowest-observed-adverse-effect level
MMA: monomethylarsonic acid
MN: micronuclei
MNPCE: micronucleated polychromatic erythrocyte
MTD: maximum tolerated dose
NAG: N-acetyl-β-D-glucosaminidase
NCEA: National Center for Environmental Assessment
NCI: National Cancer Institute
NIEHS: National Institute of Environmental Health Sciences
NOAEL: no-observed-adverse-effect level
NTP: National Toxicology Program
NZW: New Zealand White (rabbit breed)
OCT: ornithine carbamoyl transferase
ORD: Office of Research and Development
PBPK: physiologically based pharmacokinetic
PCNA: proliferating cell nuclear antigen
POD: point of departure
POD_[ADJ]_: duration-adjusted POD
QSAR: quantitative structure-activity relationship
RDS: replicative DNA synthesis
RfC: inhalation reference concentration
RfD: oral reference dose
RGDR: regional gas dose ratio
RNA: ribonucleic acid
RRB: relative risk over the background exposure
SAR: structure activity relationship
SCE: sister chromatid exchange
SD: standard deviation
SDH: sorbitol dehydrogenase
SE: standard error
SGOT: glutamic oxaloacetic transaminase, also known as AST
SGPT: glutamic pyruvic transaminase, also known as ALT
SSD: systemic scleroderma
TCA: trichloroacetic acid
TCE: trichloroethylene
TWA: time-weighted average
UF: uncertainty factor
UF_A_: animal-to-human uncertainty factor
UF_H_: human variation uncertainty factor
UF_L_: LOAEL-to-NOAEL uncertain factor
UF_S_: subchronic-to-chronic uncertainty factor
UF_D_: database deficiencies uncertainty factor
U.S.: United States