# Supplementary Materials

- Chapter 8—Body Weight Studies (PDF)
- IRIS Toxicological Review of Inorganic Arsenic Supplemental Information (PDF)
- IRIS Toxicological Review of Inorganic Arsenic (PDF)
- ORD Staff Handbook for Developing IRIS Assessments (PDF)
- Guidelines for Carcinogen Risk Assessment (PDF)