# REFERENCES

AACC (American Association for Clinical Chemistry). (1992). Clinical pathology testing recommendations for nonclinical toxicity and safety studies. Toxicol Pathol 20: 539–543.1296288
Abraham, K; El-Khatib, AH; Schwerdtle, T; Monien, BH. (2021). Perfluorobutanoic acid (PFBA): No high-level accumulation in human lung and kidney tissue. Int J Hyg Environ Health 237: 113830. 10.1016/j.ijheh.2021.113830.34450542
Amacher, DE; Schomaker, SJ; Burkhardt, JE. (1998). The relationship among microsomal enzyme induction, liver weight and histological change in rat toxicology studies. Food Chem Toxicol 36: 831–839. 10.1016/S0278-6915(98)00066-0.9737431
Anderson, JK; Luz, AL; Goodrum, P; Durda, J. (2019). Perfluorohexanoic acid toxicity, part II: Application of human health toxicity value for risk characterization. Regul Toxicol Pharmacol 103: 10–20. 10.1016/j.yrtph.2019.01.020.30634020
Anderson, RH; Long, GC; Porter, RC; Anderson, JK. (2016). Occurrence of select perfluoroalkyl substances at U.S. Air Force aqueous film-forming foam release sites other than fire-training areas: Field-validation of critical fate and transport properties. Chemosphere 150: 678–685. 10.1016/j.chemosphere.2016.01.014.26786021
ATSDR (Agency for Toxic Substances and Disease Registry). (2018). Toxicological profile for perfluoroalkyls. Draft for public comment [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention. https://www.atsdr.cdc.gov/toxprofiles/tp200.pdf.
ATSDR (Agency for Toxic Substances and Disease Registry). (2021). Toxicological profile for perfluoroalkyls [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. 10.15620/cdc:59198.
Baduel, C; Paxman, CJ; Mueller, JF. (2015). Perfluoroalkyl substances in a firefighting training ground (FTG), distribution and potential future release. J Hazard Mater 296: 46–53. 10.1016/j.jhazmat.2015.03.007.25966923
Bailey, SA; Zidell, RH; Perry, RW. (2004). Relationships between organ weight and body/brain weight in the rat: What is the best analytical endpoint? Toxicol Pathol 32: 448–466. 10.1080/01926230490465874.15204968
Bao, WW; Qian, ZM; Geiger, SD; Liu, E; Liu, Y; Wang, SQ; Lawrence, WR; Yang, BY; Hu, LW; Zeng, XW; Dong, GH. (2017). Gender-specific associations between serum isomers of perfluoroalkyl substances and blood pressure among Chinese: Isomers of C8 Health Project in China. Sci Total Environ 607–608: 1304–1312. 10.1016/j.scitotenv.2017.07.124.
Barker, DJ. (2004). The developmental origins of chronic adult disease [Review]. 93: 26–33.
Behr, AC; Plinsch, C; Braeuning, A; Buhrke, T. (2020). Activation of human nuclear receptors by perfluoroalkylated substances (PFAS). Toxicol In Vitro 62: 104700. 10.1016/j.tiv.2019.104700.31676336
Benskin, JP; De Silva, AO; Martin, LJ; Arsenault, G; Mccrindle, R; Riddell, N; Mabury, SA; Martin, JW. (2009). Disposition of perfluorinated acid isomers in Sprague-Dawley rats; part 1: single dose. Environ Toxicol Chem 28: 542–554. 10.1897/08-239.1.18939892
Bergwerk, AJ; Shi, X; Ford, AC; Kanai, N; Jacquemin, E; Burk, RD; Bai, S; Novikoff, PM; Stieger, B; Meier, PJ; Schuster, VL; Wolkoff, AW. (1996). Immunologic distribution of an organic anion transport protein in rat liver and kidney. Am J Physiol 271: G231–G238. 10.1152/ajpgi.1996.271.2.G231.8770038
Bischel, HN; Macmanus-Spencer, LA; Zhang, CJ; Luthy, RG. (2011). Strong associations of short-chain perfluoroalkyl acids with serum albumin and investigation of binding mechanisms. Environ Toxicol Chem 30: 2423–2430. 10.1002/etc.647.21842491
Bjork, JA; Wallace, KB. (2009). Structure-Activity Relationships and Human Relevance for Perfluoroalkyl Acid-Induced Transcriptional Activation of Peroxisome Proliferation in Liver Cell Cultures. Toxicol Sci 111: 89–99. 10.1093/toxsci/kfp093.19407336
Blaine, AC; Rich, CD; Hundal, LS; Lau, C; Mills, MA; Harris, KM; Higgins, CP. (2013). Uptake of perfluoroalkyl acids into edible crops via land applied biosolids: field and greenhouse studies. Environ Sci Technol 47: 14062–14069. 10.1021/es403094q.24206563
Boron, W; Boulpaep, E. (2017). Medical physiology. In Medical Physiology (3rd ed.). Philadelphia, PA: Elsevier. https://www.elsevier.com/books/medical-physiology/boron/978-1-4557-4377-3.
Bräunig, J; Baduel, C; Heffernan, A; Rotander, A; Donaldson, E; Mueller, JF. (2017). Fate and redistribution of perfluoroalkyl acids through AFFF-impacted groundwater. Sci Total Environ 596–597: 360–368. 10.1016/j.scitotenv.2017.04.095.
Brust, V; Schindler, PM; Lewejohann, L. (2015). Lifetime development of behavioural phenotype in the house mouse (Mus musculus). Frontiers in Zoology 12: S17. 10.1186/1742-9994-12-S1-S17.26816516
Buck, R; Gannon, S. (2017). Perfluorohexanoic acid pharmacokinetics in mouse, rat, microminipig, pig, monkey and human. In Abstracts of Papers of the 253rd National meeting of the American Chemical Society. Washington, DC: American Chemical Society.
Buhrke, T; Kibellus, A; Lampen, A. (2013). In vitro toxicological characterization of perfluorinated carboxylic acids with different carbon chain lengths. Toxicol Lett 218: 97–104. 10.1016/j.toxlet.2013.01.025.23391484
Burkemper, JL; Aweda, TA; Rosenberg, AJ; Lunderberg, DM; Peaslee, GF; Lapi, SE. (2017). Radiosynthesis and biological distribution of F-18-labeled perfluorinated alkyl substances. Environ Sci Technol Lett 4: 211–215. 10.1021/acs.estlett.7b00042.
Chang, S; Das, K; Ehresman, DJ; Ellefson, ME; Gorman, GS; Hart, JA; Noker, PE; Tan, Y; Lieder, PH; Lau, C; Olsen, GW; Butenhoff, JL. (2008). Comparative pharmacokinetics of perfluorobutyrate in rats, mice, monkeys, and humans and relevance to human exposure via drinking water. Toxicol Sci 104: 40–53. 10.1093/toxsci/kfn057.18353799
Chen, WL; Bai, FY; Chang, YC; Chen, PC; Chen, CY. (2018). Concentrations of perfluoroalkyl substances in foods and the dietary exposure among Taiwan general population and pregnant women. J Food Drug Anal 26: 994–1004. 10.1016/j.jfda.2017.12.011.29976417
Chengelis, CP; Kirkpatrick, JB; Myers, NR; Shinohara, M; Stetson, PL; Sved, DW. (2009a). Comparison of the toxicokinetic behavior of perfluorohexanoic acid (PFHxA) and nonafluorobutane-1-sulfonic acid (PFBS) in cynomolgus monkeys and rats. Reprod Toxicol 27: 400–406. 10.1016/j.reprotox.2009.01.013.19429410
Chengelis, CP; Kirkpatrick, JB; Radovsky, A; Shinohara, M. (2009b). A 90-day repeated dose oral (gavage) toxicity study of perfluorohexanoic acid (PFHxA) in rats (with functional observational battery and motor activity determinations). Reprod Toxicol 27: 342–351. 10.1016/j.reprotox.2009.01.006.19429405
Craig, EA; Yan, Z; Zhao, QJ. (2015). The relationship between chemical-induced kidney weight increases and kidney histopathology in rats. J Appl Toxicol 35: 729–736. 10.1002/jat.3036.25092041
Crofton, KM. (2004). Developmental disruption of thyroid hormone: Correlations with hearing dysfunction in rats. Risk Anal 24: 1665–1671. 10.1111/j.0272-4332.2004.00557.x.15660619
D’eon, JC; Simpson, AJ; Kumar, R; Baer, AJ; Mabury, SA. (2010). Determining the molecular interactions of perfluorinated carboxylic acids with human sera and isolated human serum albumin using nuclear magnetic resonance spectroscopy. Environ Toxicol Chem 29: 1678–1688. 10.1002/etc.204.20821619
Daikin Industries (Daikin Industries Limited). (2009a). The excretion and tissue distribution of [14C]-ammonium perflourohexanoate in the mouse and the rat following a multiple oral administration of 50 mg/kg. Osaka, Japan.
Daikin Industries (Daikin Industries Limited). (2009b). The excretion of [14C]-ammonium perfluorohexanoate in the mouse and the rat following a single oral administration at 50 mg/kg. Osaka, Japan.
Daikin Industries (Daikin Industries Limited). (2010). Oral (gavage) acute pharmacokinetic study of PFH ammonium salt (ammonium salt of perflourinated hexanoic acid) in mice. Osaka, Japan.
Das, KP; Wood, CR; Lin, MT; Starkov, AA; Lau, C; Wallace, KB; Corton, JC; Abbott, BD. (2017). Perfluoroalkyl acids-induced liver steatosis: Effects on genes controlling lipid homeostasis. Toxicology 378: 37–52. 10.1016/j.tox.2016.12.007.28049043
De Silva, AO; Benskin, JP; Martin, LJ; Arsenault, G; Mccrindle, R; Riddell, N; Martin, JW; Mabury, SA. (2009). Disposition of perfluorinated acid isomers in Sprague-Dawley rats; part 2: subchronic dose. Environ Toxicol Chem 28: 555–567. 10.1897/08-254.1.18939893
Dewitt, JC; Blossom, SJ; Schaider, LA. (2019). Exposure to per-fluoroalkyl and polyfluoroalkyl substances leads to immunotoxicity: epidemiological and toxicological evidence [Review]. J Expo Sci Environ Epidemiol 29: 148–156. 10.1038/s41370-018-0097-y.30482935
Döhler, KD; Wong, CC; von Zur Mühlen, A. (1979). The rat as model for the study of drug effects on thyroid function: Consideration of methodological problems [Review]. Pharmacol Ther 5: 305–318.
Dong, GH; Tung, KY; Tsai, CH; Liu, MM; Wang, D; Liu, W; Jin, YH; Hsieh, WS; Lee, YL; Chen, PC. (2013). Serum polyfluoroalkyl concentrations, asthma outcomes, and immunological markers in a case-control study of Taiwanese children. Environ Health Perspect 121: 507–513, 513e501–508. 10.1289/ehp.1205351.23309686
Dzierlenga, AL; Robinson, VG; Waidyanatha, S; Devito, MJ; Eifrid, MA; Gibbs, ST; Granville, CA; Blystone, CR. (2019). Toxicokinetics of perfluorohexanoic acid (PFHxA), perfluorooctanoic acid (PFOA) and perfluorodecanoic acid (PFDA) in male and female Hsd:Sprague dawley SD rats following intravenous or gavage administration. Xenobiotica 50: 1–11. 10.1080/00498254.2019.1683776.31625424
Emerce, E; Çetin, Ö. (2018). Genotoxicity assessment of perfluoroalkyl substances on human sperm. Toxicol Ind Health 34: 748233718799191. 10.1177/0748233718799191.
Ericson, I; Gómez, M; Nadal, M; van Bavel, B; Lindström, G; Domingo, JL. (2007). Perfluorinated chemicals in blood of residents in Catalonia (Spain) in relation to age and gender: a pilot study. Environ Int 33: 616–623. 10.1016/j.envint.2007.01.003.17289145
Eriksen, KT; Raaschou-Nielsen, O; Sørensen, M; Roursgaard, M; Loft, S; Møller, P. (2010). Genotoxic potential of the perfluorinated chemicals PFOA, PFOS, PFBS, PFNA and PFHxA in human HepG2 cells. Mutat Res 700: 39–43. 10.1016/j.mrgentox.2010.04.024.20451658
Espinosa, JS; Stryker, MP. (2012). Development and plasticity of the primary visual cortex [Review]. Neuron 75: 230–249. 10.1016/j.neuron.2012.06.009.22841309
Fàbrega, F; Kumar, V; Benfenati, E; Schuhmacher, M; Domingo, JL; Nadal, M. (2015). Physiologically based pharmacokinetic modeling of perfluoroalkyl substances in the human body. Toxicol Environ Chem 97: 814–827. 10.1080/02772248.2015.1060976.
Faix, JD. (2013). Principles and pitfalls of free hormone measurements [Review]. Best Pract Res Clin Endocrinol Metab 27: 631–645. 10.1016/j.beem.2013.06.007.24094635
Filer, D. (2015). The Toxcast™ analysis pipeline: An R package for processing and modeling chemical screening data. Washington, DC: Environmental Protection Agency. https://www.epa.gov/sites/production/files/2015-08/documents/pipeline_overview.pdf.
Filer, DL; Kothiya, P; Setzer, RW; Judson, RS; Martin, MT. (2016). tcpl: The ToxCast Pipeline for High-Throughput Screening Data. Bioinformatics 33: 618–620. 10.1093/bioinformatics/btw680.
Foreman, JE; Chang, SC; Ehresman, DJ; Butenhoff, JL; Anderson, CR; Palkar, PS; Kang, BH; Gonzalez, FJ; Peters, JM. (2009). Differential Hepatic Effects of Perfluorobutyrate Mediated by Mouse and Human PPAR-alpha. Toxicol Sci 110: 204–211. 10.1093/toxsci/kfp077.19359353
Fraser, AJ; Webster, TF; Watkins, DJ; Strynar, MJ; Kato, K; Calafat, AM; Vieira, VM; Mcclean, MD. (2013). Polyfluorinated compounds in dust from homes, offices, and vehicles as predictors of concentrations in office workers’ serum. Environ Int 60: 128–136. 10.1016/j.envint.2013.08.012.24041736
Fu, Y; Wang, T; Fu, Q; Wang, P; Lu, Y. (2014). Associations between serum concentrations of perfluoroalkyl acids and serum lipid levels in a Chinese population. Ecotoxicol Environ Saf 106: 246–252. 10.1016/j.ecoenv.2014.04.039.24863755
Fujii, Y; Niisoe, T; Harada, KH; Uemoto, S; Ogura, Y; Takenaka, K; Koizumi, A. (2015). Toxicokinetics of perfluoroalkyl carboxylic acids with different carbon chain lengths in mice and humans. J Occup Health 57: 1–12. 10.1539/joh.14-0136-OA.25422127
Gaballah, S; Swank, A; Sobus, JR; Howey, XM; Schmid, J; Catron, T; Mccord, J; Hines, E; Strynar, M; Tal, T. (2020). Evaluation of developmental toxicity, developmental neurotoxicity, and tissue dose in zebrafish exposed to GenX and other PFAS. Environ Health Perspect 128: 47005. 10.1289/EHP5843.32271623
Gannon, SA; Johnson, T; Nabb, DL; Serex, TL; Buck, RC; Loveless, SE. (2011). Absorption, distribution, metabolism, and excretion of [1-^14^C]-perfluorohexanoate ([^14^C]-PFHx) in rats and mice. Toxicology 283: 55–62. 10.1016/j.tox.2011.02.004.21349313
Gilbert, ME. (2011). Impact of low-level thyroid hormone disruption induced by propylthiouracil on brain development and function. Toxicol Sci 124: 432–445. 10.1093/toxsci/kfr244.21964421
Gilbert, ME; Sanchez-Huerta, K; Wood, C. (2016). Mild thyroid hormone insufficiency during development compromises activity-dependent neuroplasticity in the hippocampus of adult male rats : Supplemental data [Supplemental Data]. Endocrinology 157: 774–787.26606422
Glüge, J; Scheringer, M; Cousins, IT; Dewitt, JC; Goldenman, G; Herzke, D; Lohmann, R; Ng, CA; Trier, X; Wang, Z. (2020). An overview of the uses of per- and polyfluoroalkyl substances (PFAS). Environ Sci Process Impacts 22: 2345–2373. 10.1039/d0em00291g.33125022
Gomis, MI; Vestergren, R; Borg, D; Cousins, IT. (2018). Comparing the toxic potency in vivo of long-chain perfluoroalkyl acids and fluorinated alternatives. Environ Int 113: 1–9. 10.1016/j.envint.2018.01.011.29421396
Goodrow, SM; Ruppel, B; Lippincott, RL; Post, GB; Procopio, NA. (2020). Investigation of levels of perfluoroalkyl substances in surface water, sediment and fish tissue in New Jersey, USA. Sci Total Environ 729: 138839. 10.1016/j.scitotenv.2020.138839.32387771
Gotoh, Y; Kato, Y; Stieger, B; Meier, PJ; Sugiyama, Y. (2002). Gender difference in the Oatp1-mediated tubular reabsorption of estradiol 17beta-D-glucuronide in rats. Am J Physiol Endocrinol Metab 282: E1245–E1254. 10.1152/ajpendo.00363.2001.12006354
Guo, X; Zhang, S; Liu, X; Lu, S; Wu, Q; Xie, P. (2021). Evaluation of the acute toxicity and neurodevelopmental inhibition of perfluorohexanoic acid (PFHxA) in zebrafish embryos. Ecotoxicol Environ Saf 225: 112733. 10.1016/j.ecoenv.2021.112733.34478978
Guyatt, G; Oxman, AD; Akl, EA; Kunz, R; Vist, G; Brozek, J; Norris, S; Falck-Ytter, Y; Glasziou, P; DeBeer, H; Jaeschke, R; Rind, D; Meerpohl, J; Dahm, P; Schünemann, HJ. (2011). GRADE guidelines: 1. Introduction-GRADE evidence profiles and summary of findings tables. J Clin Epidemiol 64: 383–394. 10.1016/j.jclinepi.2010.04.026.21195583
Haddow, JE; Palomaki, GE; Allan, WC; Williams, JR; Knight, GJ; Gagnon, J; O’Heir, CE; Mitchell, ML; Hermos, RJ; Waisbren, SE; Faix, JD; Klein, RZ. (1999). Maternal thyroid deficiency during pregnancy and subsequent neuropsychological development of the child. N Engl J Med 341: 549–555. 10.1056/NEJM199908193410801.10451459
Hall, AP; Elcombe, CR; Foster, JR; Harada, T; Kaufmann, W; Knippel, A; Küttler, K; Malarkey, DE; Maronpot, RR; Nishikawa, A; Nolte, T; Schulte, A; Strauss, V; York, MJ. (2012). Liver hypertrophy: a review of adaptive (adverse and non-adverse) changes--conclusions from the 3rd International ESTP Expert Workshop [Review]. Toxicol Pathol 40: 971–994. 10.1177/0192623312448935.22723046
Hamers, T; Kortenkamp, A; Scholze, M; Molenaar, D; Cenijn, PH; Weiss, JM. (2020). Transthyretin-Binding Activity of Complex Mixtures Representing the Composition of Thyroid-Hormone Disrupting Contaminants in House Dust and Human Serum. Environ Health Perspect 128. 10.1289/EHP5911.
Han, X; Nabb, DL; Russell, MH; Kennedy, GL; Rickard, RW. (2012). Renal elimination of perfluorocarboxylates (PFCAs) [Review]. Chem Res Toxicol 25: 35–46. 10.1021/tx200363w.21985250
Hata, S; Wang, P; Eftychiou, N; Ananthanarayanan, M; Batta, A; Salen, G; Pang, KS; Wolkoff, AW. (2003). Substrate specificities of rat oatp1 and ntcp: implications for hepatic organic anion uptake. Am J Physiol Gastrointest Liver Physiol 285: G829–G839. 10.1152/ajpgi.00352.2002.12842829
Heo, JJ; Lee, JW; Kim, SK; Oh, JE. (2014). Foodstuff analyses show that seafood and water are major perfluoroalkyl acids (PFAAs) sources to humans in Korea. J Hazard Mater 279: 402–409. 10.1016/j.jhazmat.2014.07.004.25093550
Hill, AB. (1965). The environment and disease: Association or causation? Proc R Soc Med 58: 295–300.14283879
Hood, A; Hashmi, R; Klaassen, CD. (1999). Effects of microsomal enzyme inducers on thyroid-follicular cell proliferation, hyperplasia, and hypertrophy. Toxicol Appl Pharmacol 160: 163–170. 10.1006/taap.1999.8752.10527915
Houtz, EF; Higgins, CP; Field, JA; Sedlak, DL. (2013). Persistence of perfluoroalkyl acid precursors in AFFF-impacted groundwater and soil. Environ Sci Technol 47: 8187–8195. 10.1021/es4018877.23886337
IPCS (International Programme on Chemical Safety). (2012). Harmonization project document no. 10: Guidance for immunotoxicity risk assessment for chemicals. (Harmonization Project Document No. 10). Geneva, Switzerland: World Health Organization. http://www.inchem.org/documents/harmproj/harmproj/harmproj10.pdf.
Iwabuchi, K; Senzaki, N; Mazawa, D; Sato, I; Hara, M; Ueda, F; Liu, W; Tsuda, S. (2017). Tissue toxicokinetics of perfluoro compounds with single and chronic low doses in male rats. J Toxicol Sci 42: 301–317. 10.2131/jts.42.301.28496036
Iwai, H. (2011). Toxicokinetics of ammonium perfluorohexanoate. Drug Chem Toxicol 34: 341–346. 10.3109/01480545.2011.585162.21696261
Iwai, H; Hoberman, AM. (2014). Oral (Gavage) Combined Developmental and Perinatal/Postnatal Reproduction Toxicity Study of Ammonium Salt of Perfluorinated Hexanoic Acid in Mice. Int J Toxicol 33: 219–237. 10.1177/1091581814529449.24700568
Janků, I,. (1993). Physiological modelling of renal drug clearance. Eur J Clin Pharmacol 44: 513–519. 10.1007/BF02440850.8405004
Janků, I; Zvára, K. (1993). Quantitative analysis of drug handling by the kidney using a physiological model of renal drug clearance. Eur J Clin Pharmacol 44: 521–524.8405005
Jiang, L; Hong, Y; Xie, G; Zhang, J; Zhang, H; Cai, Z. (2021). Comprehensive multi-omics approaches reveal the hepatotoxic mechanism of perfluorohexanoic acid (PFHxA) in mice. Sci Total Environ 790: 148160. 10.1016/j.scitotenv.2021.148160.34380288
Jiang, W; Zhang, Y; Zhu, L; Deng, J. (2014). Serum levels of perfluoroalkyl acids (PFAAs) with isomer analysis and their associations with medical parameters in Chinese pregnant women. Environ Int 64: 40–47. 10.1016/j.envint.2013.12.001.24361923
Jin, H; Mao, L; Xie, J; Zhao, M; Bai, X; Wen, J; Shen, T; Wu, P. (2020). Poly- and perfluoroalkyl substance concentrations in human breast milk and their associations with postnatal infant growth. Sci Total Environ 713: 136417. 10.1016/j.scitotenv.2019.136417.31955077
Jin, H; Zhang, Y; Jiang, W; Zhu, L; Martin, JW. (2016). Isomer-Specific Distribution of Perfluoroalkyl Substances in Blood. Environ Sci Technol 50: 7808–7815. 10.1021/acs.est.6b01698.27295125
Kabadi, SV; Fisher, J; Aungst, J; Rice, P. (2018). Internal exposure-based pharmacokinetic evaluation of potential for biopersistence of 6:2 fluorotelomer alcohol (FTOH) and its metabolites. Food Chem Toxicol 112: 375–382. 10.1016/j.fct.2018.01.012.29331735
Kajantie, E; Osmond, C; Barker, DJP; Forsen, T; Phillips, DIW; Eriksson, JG. (2005). Size at birth as a predictor of mortality in adulthood: a follow-up of 350 000 person-years. Int J Epidemiol 34: 655–663. 10.1093/ije/dyi048.15764690
Karásková, P; Venier, M; Melymuk, L; Bečanová, J; Vojta, Š; Prokeš, R; Diamond, ML; Klánová, J. (2016). Perfluorinated alkyl substances (PFASs) in household dust in Central Europe and North America. Environ Int 94: 315–324. 10.1016/j.envint.2016.05.031.27295048
Kato, K; Calafat, AM; Needham, LL. (2009). Polyfluoroalkyl chemicals in house dust. Environ Res 109: 518–523. 10.1016/j.envres.2009.01.005.19261270
Kim, DH; Kim, UJ; Kim, HY; Choi, SD; Oh, JE. (2016a). Perfluoroalkyl substances in serum from South Korean infants with congenital hypothyroidism and healthy infants - Its relationship with thyroid hormones. Environ Res 147: 399–404. 10.1016/j.envres.2016.02.037.26950028
Kim, M; Park, MS; Son, J; Park, I; Lee, HK; Kim, C; Min, BH; Ryoo, J; Choi, KS; Lee, DS; Lee, HS. (2015). Perfluoroheptanoic acid affects amphibian embryogenesis by inducing the phosphorylation of ERK and JNK. Int J Mol Med 36: 1693–1700. 10.3892/ijmm.2015.2370.26459765
Kim, SJ; Heo, SH; Lee, DS; Hwang, IG; Lee, YB; Cho, HY. (2016b). Gender differences in pharmacokinetics and tissue distribution of 3 perfluoroalkyl and polyfluoroalkyl substances in rats. Food Chem Toxicol 97: 243–255. 10.1016/j.fct.2016.09.017.27637925
Kirkpatrick, JB. (2005a). Final report: A combined 28-day repeated dose oral toxicity study with reproductive/developmental screening study test of perfluorohexanoic acid and 1H,1H,2H,2H-tridecafluoro-1-octanol in rats, with recovery. Ashland, OH: WIL Research Laboratories. https://www.agc-chemicals.com/jp/en/fluorine/products/detail/feature/index.html?pCode=JP-EN-F001.
Kirkpatrick, JB. (2005b). Final report: A combined 28-day repeated dose oral toxicity study with reproductive/developmental screening study test of perfluorohexanoic acid and 1H,1H,2H,2H-tridecafluoro-1-octanol in rats, with recovery (Volume 1 of 6, Text and tables 1-75). Ashland, OH: WIL Research Laboratories. https://www.agc-chemicals.com/jp/en/fluorine/products/detail/feature/index.html?pCode=JP-EN-F001.
Kirkpatrick, JB. (2005c). Final report: A combined 28-day repeated dose oral toxicity study with reproductive/developmental screening study test of perfluorohexanoic acid and 1H,1H,2H,2H-tridecafluoro-1-octanol in rats, with recovery (Volume 2 of 6, Tables 76-110). Ashland, OH: WIL Research Laboratories. https://www.agc-chemicals.com/jp/en/fluorine/products/detail/feature/index.html?pCode=JP-EN-F001.
Kirkpatrick, JB. (2005d). Final report: A combined 28-day repeated dose oral toxicity study with reproductive/developmental screening study test of perfluorohexanoic acid and 1H,1H,2H,2H-tridecafluoro-1-octanol in rats, with recovery (Volume 3 of 6, Tables 111-119). Ashland, OH: WIL Research Laboratories. https://www.agc-chemicals.com/jp/en/fluorine/products/detail/feature/index.html?pCode=JP-EN-F001.
Kirkpatrick, JB. (2005e). Final report: A combined 28-day repeated dose oral toxicity study with reproductive/developmental screening study test of perfluorohexanoic acid and 1H,1H,2H,2H-tridecafluoro-1-octanol in rats, with recovery (Volume 4 of 6, Tables 120-144). Ashland, OH: WIL Research Laboratories. https://www.agc-chemicals.com/jp/en/fluorine/products/detail/feature/index.html?pCode=JP-EN-F001.
Kirkpatrick, JB. (2005f). Final report: A combined 28-day repeated dose oral toxicity study with reproductive/developmental screening study test of perfluorohexanoic acid and 1H,1H,2H,2H-tridecafluoro-1-octanol in rats, with recovery (Volume 5 of 6, Appendices AH). Ashland, OH: WIL Research Laboratories. https://www.agc-chemicals.com/jp/en/fluorine/products/detail/feature/index.html?pCode=JP-EN-F001.
Kirkpatrick, JB. (2005g). Final report: A combined 28-day repeated dose oral toxicity study with reproductive/developmental screening study test of perfluorohexanoic acid and 1H,1H,2H,2H-tridecafluoro-1-octanol in rats, with recovery (Volume 6 of 6, Appendices I-L). Ashland, OH: WIL Research Laboratories. https://www.agc-chemicals.com/jp/en/fluorine/products/detail/feature/index.html?pCode=JP-EN-F001.
Klaunig, JE; Shinohara, M; Iwai, H; Chengelis, CP; Kirkpatrick, JB; Wang, Z; Bruner, RH. (2015). Evaluation of the chronic toxicity and carcinogenicity of perfluorohexanoic acid (PFHxA) in Sprague-Dawley rats. Toxicol Pathol 43: 209–220. 10.1177/0192623314530532.25377447
Knobeloch, L; Imm, P; Anderson, H. (2012). Perfluoroalkyl chemicals in vacuum cleaner dust from 39 Wisconsin homes. Chemosphere 88: 779–783. 10.1016/j.chemosphere.2012.03.082.22542201
Kudo, N. (2015). Metabolism and pharmacokinetics. In JC DeWitt (Ed.), Toxicological Effects of Perfluoroalkyl and Polyfluoroalkyl Substances (pp. 151–175). New York, NY: Springer International Publishing. 10.1007/978-3-319-15518-0_6.
Kudo, N; Katakura, M; Sato, Y; Kawashima, Y. (2002). Sex hormone-regulated renal transport of perfluorooctanoic acid. Chem Biol Interact 139: 301–316. 10.1016/S0009-2797(02)00006-6.11879818
Kudo, N; Suzuki, E; Katakura, M; Ohmori, K; Noshiro, R; Kawashima, Y. (2001). Comparison of the elimination between perfluorinated fatty acids with different carbon chain length in rats. Chem Biol Interact 134: 203–216. 10.1016/S0009-2797(01)00155-7.11311214
Lau, C; Butenhoff, JL; Rogers, JM. (2004). The developmental toxicity of perfluoroalkyl acids and their derivatives [Review]. Toxicol Appl Pharmacol 198: 231–241. 10.1016/j.taap.2003.11.031.15236955
Lau, C; Thibodeaux, JR; Hanson, RG; Narotsky, MG; Rogers, JM; Lindstrom, AB; Strynar, MJ. (2006). Effects of perfluorooctanoic acid exposure during pregnancy in the mouse. Toxicol Sci 90: 510–518. 10.1093/toxsci/kfj105.16415327
Lau, C; Thibodeaux, JR; Hanson, RG; Rogers, JM; Grey, BE; Stanton, ME; Butenhoff, JL; Stevenson, LA. (2003). Exposure to perfluorooctane sulfonate during pregnancy in rat and mouse. II: postnatal evaluation. Toxicol Sci 74: 382–392. 10.1093/toxsci/kfg122.12773772
Li, J; Cai, D; Chu, C; Li, QQ; Zhou, Y; Hu, LW; Yang, BY; Dong, GH; Zeng, XW; Chen, D. (2020). Transplacental Transfer of Per- and Polyfluoroalkyl Substances (PFASs): Differences between Preterm and Full-Term Deliveries and Associations with Placental Transporter mRNA Expression. Environ Sci Technol 54: 5062–5070. 10.1021/acs.est.0c00829.32208722
Li, Y; Cheng, Y; Xie, Z; Zeng, F. (2017). Perfluorinated alkyl substances in serum of the southern Chinese general population and potential impact on thyroid hormones. Sci Rep 7: 43380. 10.1038/srep43380.28240244
Liu, JJ; Cui, XX; Tan, YW; Dong, PX; Ou, YQ; Li, QQ; Chu, C; Wu, LY; Liang, LX; Qin, SJ; Zeeshan, M; Zhou, Y; Hu, LW; Liu, RQ; Zeng, XW; Dong, GH; Zhao, XM. (2022). Per- and perfluoroalkyl substances alternatives, mixtures and liver function in adults: A community-based population study in China. Environ Int 163: 107179. 10.1016/j.envint.2022.107179.35325771
Loveless, SE; Slezak, B; Serex, T; Lewis, J; Mukerji, P; O’Connor, JC; Donner, EM; Frame, S. R.; Korzeniowski, SH; Buck, RC. (2009). Toxicological evaluation of sodium perfluorohexanoate. Toxicology 264: 32–44. 10.1016/j.tox.2009.07.011.19632293
Lu, R; Kanai, N; Bao, Y; Wolkoff, AW; Schuster, VL. (1996). Regulation of renal oatp mRNA expression by testosterone. Am J Physiol 270: F332–F337. 10.1152/ajprenal.1996.270.2.F332.8779895
Luz, AL; Anderson, JK; Goodrum, P; Durda, J. (2019). Perfluorohexanoic acid toxicity, part I: Development of a chronic human health toxicity value for use in risk assessment. Regul Toxicol Pharmacol 103: 41–55. 10.1016/j.yrtph.2019.01.019.30639337
MDH (Minnesota Department of Health). (2018). Health based guidance for water: Perfluorooctanoic acid toxicological summary. Health Risk Assessment Unit, Environmental Health Division, Minnesota Department of Health. https://www.health.state.mn.us/communities/environment/risk/docs/guidance/gw/pfoa.pdf.
MDH (Minnesota Department of Health). (2019). Health Based Guidance for Water: Toxicological Summary for: Perfluorohexane sulfonate (PFHxS). https://www.health.state.mn.us/communities/environment/risk/docs/guidance/gw/pfhxs.pdf.
MDH (Minnesota Department of Health). (2020). Health Based Guidance for Water: Toxicological Summary for: Perfluorooctane Sulfonate (PFOS). https://www.health.state.mn.us/communities/environment/risk/docs/guidance/gw/pfos.pdf.
Moreta, C; Tena, MT. (2014). Determination of perfluorinated alkyl acids in corn, popcorn and popcorn bags before and after cooking by focused ultrasound solid-liquid extraction, liquid chromatography and quadrupole-time of flight mass spectrometry. J Chromatogr A 1355: 211–218. 10.1016/j.chroma.2014.06.018.24986069
Morgan, RL; Thayer, KA; Bero, L; Bruce, N; Falck-Ytter, Y; Ghersi, D; Guyatt, G; Hooijmans, C; Langendam, M; Mandrioli, D; Mustafa, RA; Rehfuess, EA; Rooney, AA; Shea, B; Silbergeld, EK; Sutton, P; Wolfe, MS; Woodruff, TJ; Verbeek, JH; Holloway, AC; Santesso, N; Schünemann, HJ. (2016). GRADE: Assessing the quality of evidence in environmental and occupational health. Environ Int 92–93: 611–616. 10.1016/j.envint.2016.01.004.
Naile, JE; Wiseman, S; Bachtold, K; Jones, PD; Giesy, JP. (2012). Transcriptional effects of perfluorinated compounds in rat hepatoma cells. Chemosphere 86: 270–277. 10.1016/j.chemosphere.2011.09.044.22071372
Nian, M; Li, QQ; Bloom, M; Qian, ZM; Syberg, KM; Vaughn, MG; Wang, SQ; Wei, Q; Zeeshan, M; Gurram, N; Chu, C; Wang, J; Tian, YP; Hu, LW; Liu, KK; Yang, BY; Liu, RQ; Feng, D; Zeng, XW; Dong, GH. (2019). Liver function biomarkers disorder is associated with exposure to perfluoroalkyl acids in adults: Isomers of C8 Health Project in China. Environ Res 172: 81–88. 10.1016/j.envres.2019.02.013.30776734
Nilsson, H; Kärrman, A; Rotander, A; van Bavel, B; Lindström, G; Westberg, H. (2013). Biotransformation of fluorotelomer compound to perfluorocarboxylates in humans. Environ Int 51: 8–12. 10.1016/j.envint.2012.09.001.23138016
Nilsson, H; Kärrman, A; Westberg, H; Rotander, A; van Bavel, B; Lindström, G. (2010). A time trend study of significantly elevated perfluorocarboxylate levels in humans after using fluorinated ski wax. Environ Sci Technol 44: 2150–2155. 10.1021/es9034733.20158198
NLM (National Library of Medicine). (2013). HSDB: Perfluoro-n-nonanoic acid. Available online at https://pubchem.ncbi.nlm.nih.gov/source/hsdb/8040 (accessed
NLM (National Library of Medicine). (2016). HSDB: Perfluorohexanoic acid. Available online at https://pubchem.ncbi.nlm.nih.gov/source/hsdb/8299 (accessed
NLM (National Library of Medicine). (2017). HSDB: Perfluorohexanesulfonic acid. Available online at https://pubchem.ncbi.nlm.nih.gov/source/hsdb/8274 (accessed
Nobels, I; Dardenne, F; De Coen, W, im; Blust, R. (2010). Application of a multiple endpoint bacterial reporter assay to evaluate toxicological relevant endpoints of perfluorinated compounds with different functional groups and varying chain length. Toxicol In Vitro 24: 1768–1774. 10.1016/j.tiv.2010.07.002.20619337
NTP (National Toxicology Program). (2017). Toxicokinetic evaluation (C20613) of perfluorohexanoic acid (307-24-4) in Harlan Sprague-Dawley rats exposed via gavage or intravenous injection. Durham, NC. Retrieved from https://tools.niehs.nih.gov/cebs3/views/?action=main.dataReview&bin_id=2566
NTP (National Toxicology Program). (2018). 28-day evaluation of the toxicity (C20613) of perfluorohexanoic acid (PFHxA) (307-24-4) on Harlan Sprague-Dawley rats exposed via gavage. Available online at https://tools.niehs.nih.gov/cebs3/views/?action=main.dataReview&bin_id=3879 (accessed
O’Connell, KE; Mikkola, AM; Stepanek, AM; Vernet, A; Hall, AD; Sun, CC; Yildirim, E; Staropoli, JF; Lee, JT; Brown, DE. (2015). Practical murine hematopathology: a comparative review and implications for research. Comp Med 65: 96–113.25926395
OECD (Organisation for Economic Co-operation and Development). (2015). Working towards a global emission inventory of PFASS: focus on PFCAS - status quo and the way forward. Paris, France. http://www.oecd.org/chemicalsafety/Working%20Towards%20a%20Global%20Emission%20Inventory%20of%20PFASS.pdf.
OECD (Organisation for Economic Co-operation and Development). (2022). Fact cards of major groups of per- and polyfluoroalkyl substances (PFASs). (ENV/CBC/MONO(2022)1). Paris, France: Organisation for Economic Co-operation and Development, Environment Directorate. https://www.oecd.org/officialdocuments/publicdisplaydocumentpdf/?cote=env/cbc/mono(2022)1&doclanguage=en.
Ohmori, K; Kudo, N; Katayama, K; Kawashima, Y. (2003). Comparison of the toxicokinetics between perfluorocarboxylic acids with different carbon chain length. Toxicology 184: 135–140. 10.1016/S0300-483X(02)00573-5.12499116
Olsen, GW; Burris, JM; Ehresman, DJ; Froehlich, JW; Seacat, AM; Butenhoff, JL; Zobel, LR. (2007). Half-life of serum elimination of perfluorooctanesulfonate,perfluorohexanesulfonate, and perfluorooctanoate in retired fluorochemical production workers. Environ Health Perspect 115: 1298–1305. 10.1289/ehp.10009.17805419
Olsen, GW; Chang, SC; Noker, PE; Gorman, GS; Ehresman, DJ; Lieder, PH; Butenhoff, JL. (2009). A comparison of the pharmacokinetics of perfluorobutanesulfonate (PFBS) in rats, monkeys, and humans. Toxicology 256: 65–74. 10.1016/j.tox.2008.11.008.19059455
Pérez, F; Llorca, M; Köck-Schulmeyer, M; Škrbić, B; Oliveira, LS; da Boit Martinello, K; Al-Dhabi, NA; Antić, I; Farré, M; Barceló, D. (2014). Assessment of perfluoroalkyl substances in food items at global scale. Environ Res 135: 181–189. 10.1016/j.envres.2014.08.004.25282275
Pérez, F; Nadal, M; Navarro-Ortega, A; Fàbrega, F; Domingo, JL; Barceló, D; Farré, M. (2013). Accumulation of perfluoroalkyl substances in human tissues. Environ Int 59: 354–362. 10.1016/j.envint.2013.06.004.23892228
Pierozan, P; Cattani, D; Karlsson, O. (2022). Tumorigenic activity of alternative per- and polyfluoroalkyl substances (PFAS): Mechanistic in vitro studies. Sci Total Environ 808: 151945. 10.1016/j.scitotenv.2021.151945.34843762
Poothong, S; Thomsen, C; Padilla-Sanchez, JA; Papadopoulou, E; Haug, LS. (2017). Distribution of novel and well-known poly- and perfluoroalkyl substances (PFASs) in human serum, plasma, and whole blood. Environ Sci Technol 51: 13388–13396. 10.1021/acs.est.7b03299.29056041
Post, GB; Cohn, PD; Cooper, KR. (2012). Perfluorooctanoic acid (PFOA), an emerging drinking water contaminant: a critical review of recent literature [Review]. Environ Res 116: 93–117. 10.1016/j.envres.2012.03.007.22560884
Qin, XD; Qian, ZM; Dharmage, SC; Perret, J; Geiger, SD; Rigdon, SE; Howard, S; Zeng, XW; Hu, LW; Yang, BY; Zhou, Y; Li, M; Xu, SL; Bao, WW; Zhang, YZ; Yuan, P; Wang, J; Zhang, C; Tian, YP; Nian, M; Xiao, X; Chen, W; Lee, YL; Dong, GH. (2017). Association of perfluoroalkyl substances exposure with impaired lung function in children. Environ Res 155: 15–21. 10.1016/j.envres.2017.01.025.28171771
Rayne, S; Forest, K. (2010). Theoretical studies on the pKa values of perfluoroalkyl carboxylic acids. J Mol Struct Theochem 949: 60–69. 10.1016/j.theochem.2010.03.003.
Reddy, JK. (2004). Peroxisome proliferators and peroxisome proliferator-activated receptor alpha: biotic and xenobiotic sensing. Am J Pathol 164: 2305–2321. 10.1016/s0002-9440(10)63787-x.15161663
Ren, XM; Qin, WP; Cao, LY; Zhang, J; Yang, Y; Wan, B; Guo, LH. (2016). Binding interactions of perfluoroalkyl substances with thyroid hormone transport proteins and potential toxicological implications. Toxicology 366–367: 32–42. 10.1016/j.tox.2016.08.011.
Ren, XM; Zhang, YF; Guo, LH; Qin, ZF; Lv, QY; Zhang, LY. (2015). Structure-activity relations in binding of perfluoroalkyl compounds to human thyroid hormone T3 receptor. Arch Toxicol 89: 233–242. 10.1007/s00204-014-1258-y.24819616
Riker Labs (Riker Laboratories). (1979). Acute oral toxicity screen with T-2712CoC in albino rats. Experiment no. 0479AR0680 [TSCA Submission]. (8EHQ-04-15674A; 88040000247). St. Paul, MN: 3M Company.
Rosen, MB; Das, KP; Rooney, J; Abbott, B; Lau, C; Corton, JC. (2017). PPARα-independent transcriptional targets of perfluoroalkyl acids revealed by transcript profiling. Toxicology 387: 95–107. 10.1016/j.tox.2017.05.013.28558994
Russell, MH; Himmelstein, MW; Buck, RC. (2015). Inhalation and oral toxicokinetics of 6:2 FTOH and its metabolites in mammals. Chemosphere 120: 328–335. 10.1016/j.chemosphere.2014.07.092.25180935
Russell, MH; Nilsson, H; Buck, RC. (2013). Elimination kinetics of perfluorohexanoic acid in humans and comparison with mouse, rat and monkey. Chemosphere 93: 2419–2425. 10.1016/j.chemosphere.2013.08.060.24050716
Sabolić, I; Asif, AR; Budach, WE; Wanke, C; Bahn, A; Burckhardt, G. (2007). Gender differences in kidney function [Review]. Pflugers Arch 455: 397–492. 10.1007/s00424-007-0308-1.17638010
Sanan, T; Magnuson, M. (2020). Analysis of per- and polyfluorinated alkyl sub-stances in subsampled water matrices with online solid phase extraction/isotope dilution tandem mass spectrometry. J Chromatogr A 1626: 461324. 10.1016/j.chroma.2020.461324.32797817
Sanchez Garcia, D; Sjödin, M; Hellstrandh, M; Norinder, U; Nikiforova, V; Lindberg, J; Wincent, E; Bergman, Å; Cotgreave, I; Munic Kos, V. (2018). Cellular accumulation and lipid binding of perfluorinated alkylated substances (PFASs) - A comparison with lysosomotropic drugs. Chem Biol Interact 281: 1–10. 10.1016/j.cbi.2017.12.021.29248446
Schecter, A; Malik-Bass, N; Calafat, AM; Kato, K; Colacino, JA; Gent, TL; Hynan, LS; Harris, TR; Malla, S; Birnbaum, L. (2012). Polyfluoroalkyl compounds in Texas children from birth through 12 years of age. Environ Health Perspect 120: 590–594. 10.1289/ehp.1104325.22182702
Schünemann, H; Hill, S; Guyatt, G; Akl, EA; Ahmed, F. (2011). The GRADE approach and Bradford Hill’s criteria for causation. J Epidemiol Community Health 65: 392–395. 10.1136/jech.2010.119933.20947872
Seo, SH; Son, MH; Choi, SD; Lee, DH; Chang, YS. (2018). Influence of exposure to perfluoroalkyl substances (PFASs) on the Korean general population: 10-year trend and health effects. Environ Int 113: 149–161. 10.1016/j.envint.2018.01.025.29425899
Shao, M; Ding, G; Zhang, J; Wei, L; Xue, H; Zhang, N; Li, Y; Chen, G; Sun, Y. (2016). Occurrence and distribution of perfluoroalkyl substances (PFASs) in surface water and bottom water of the Shuangtaizi Estuary, China. Environ Pollut 216: 675–681. 10.1016/j.envpol.2016.06.031.27344086
Shitara, Y; Sugiyama, D; Kusuhara, H; Kato, Y; Abe, T; Meier, PJ; Itoh, T; Sugiyama, Y. (2002). Comparative inhibitory effects of different compounds on rat oatpl (slc21a1)- and Oatp2 (Slc21a5)-mediated transport. Pharm Res 19: 147–153. 10.1023/a:1014264614637.11883641
Song, X; Tang, S; Zhu, H; Chen, Z; Zang, Z; Zhang, Y; Niu, X; Wang, X; Yin, H; Zeng, F; He, C. (2018). Biomonitoring PFAAs in blood and semen samples: Investigation of a potential link between PFAAs exposure and semen mobility in China. Environ Int 113: 50–54. 10.1016/j.envint.2018.01.010.29421407
Stahl, LL; Snyder, BD; Olsen, AR; Kincaid, TM; Wathen, JB; Mccarty, HB. (2014). Perfluorinated compounds in fish from U.S. urban rivers and the Great Lakes. Sci Total Environ 499: 185–195. 10.1016/j.scitotenv.2014.07.126.25190044
Steinle-Darling, E; Reinhard, M. (2008). Nanofiltration for trace organic contaminant removal: structure, solution, and membrane fouling effects on the rejection of perfluorochemicals. Environ Sci Technol 42: 5292–5297. 10.1021/es703207s.18754383
Strynar, MJ; Lindstrom, AB. (2008). Perfluorinated compounds in house dust from Ohio and North Carolina, USA. Environ Sci Technol 42: 3751–3756. 10.1021/es7032058.18546718
Sunderland, EM; Hu, XC; Dassuncao, C; Tokranov, AK; Wagner, CC; Allen, JG. (2019). A review of the pathways of human exposure to poly- and perfluoroalkyl substances (PFASs) and present understanding of health effects [Review]. J Expo Sci Environ Epidemiol 29: 131–147. 10.1038/s41370-018-0094-1.30470793
Sundström, M; Chang, SC; Noker, PE; Gorman, GS; Hart, JA; Ehresman, DJ; Bergman, A; Butenhoff, JL. (2012). Comparative pharmacokinetics of perfluorohexanesulfonate (PFHxS) in rats, mice, and monkeys. Reprod Toxicol 33: 441–451. 10.1016/j.reprotox.2011.07.004.21856411
Tatum-Gibbs, K; Wambaugh, JF; Das, KP; Zehr, RD; Strynar, MJ; Lindstrom, AB; Delinsky, A; Lau, C. (2011). Comparative pharmacokinetics of perfluorononanoic acid in rat and mouse. Toxicology 281: 48–55. 10.1016/j.tox.2011.01.003.21237237
Thienpont, LM; Van Uytfanghe, K; Poppe, K; Velkeniers, B. (2013). Determination of free thyroid hormones [Review]. Best Pract Res Clin Endocrinol Metab 27: 689–700. 10.1016/j.beem.2013.05.012.24094639
Thompson, JA; Regnault, TR. (2011). In utero origins of adult insulin resistance and vascular dysfunction [Review]. Seminars in Reproductive Medicine 29: 211–224. 10.1055/s-0031-1275522.21710397
Thoolen, B; Maronpot, RR; Harada, T; Nyska, A; Rousseaux, C; Nolte, T; Malarkey, DE; Kaufmann, W; Küttler, K; Deschl, U; Nakae, D; Gregson, R; Vinlove, MP; Brix, AE; Singh, B; Belpoggi, F; Ward, JM. (2010). Proliferative and nonproliferative lesions of the rat and mouse hepatobiliary system [Review]. Toxicol Pathol 38: 5S–81S. 10.1177/0192623310386499.21191096
Tian, YP; Zeng, XW; Bloom, MS; Lin, S; Wang, SQ; Yim, SHL; Yang, M; Chu, C; Gurram, N; Hu, LW; Liu, KK; Yang, BY; Feng, D; Liu, RQ; Nian, M; Dong, GH. (2019). Isomers of perfluoroalkyl substances and overweight status among Chinese by sex status: Isomers of C8 Health Project in China. Environ Int 124: 130–138. 10.1016/j.envint.2019.01.006.30641256
U.S. EPA (U.S. Environmental Protection Agency). (1991). Guidelines for developmental toxicity risk assessment. Fed Reg 56: 63798–63826.
U.S. EPA (U.S. Environmental Protection Agency). (1994). Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry [EPA Report]. (EPA600890066F). Research Triangle Park, NC. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=71993&CFID=51174829&CFTOKEN=25006317.
U.S. EPA (U.S. Environmental Protection Agency). (1998). Guidelines for neurotoxicity risk assessment [EPA Report]. (EPA/630/R-95/001F). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. http://www.epa.gov/risk/guidelines-neurotoxicity-risk-assessment.
U.S. EPA (U.S. Environmental Protection Agency). (2002a). Hepatocellular hypertrophy. HED guidance document #G2002.01 [EPA Report]. Washington, DC.
U.S. EPA (U.S. Environmental Protection Agency). (2002b). Perfluoroalkyl sulfonates; significant new use rule [SNUR]. (EPA-HQ-OPPT-2002-0043-0001). https://www.regulations.gov/document/EPA-HQ-OPPT-2002-0043-0001.
U.S. EPA (U.S. Environmental Protection Agency). (2002c). A review of the reference dose and reference concentration processes. (EPA630P02002F). Washington, DC. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2003). Toxicological review of methyl ethyl ketone (CAS No. 78-93-3): In support of summary information on the Integrated Risk Information System (IRIS). (EPA 635/R-03/009). Washington, DC. http://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0071tr.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2004). Toxicological review of boron and compounds. In support of summary information on the Integrated Risk Information System (IRIS) [EPA Report]. (EPA/635/04/052). Washington, DC: U.S. Environmental Protection Agency, IRIS. http://nepis.epa.gov/exe/ZyPURL.cgi?Dockey=P1006CK9.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2005). Guidelines for carcinogen risk assessment [EPA Report]. (EPA630P03001F). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3-25-05.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2007). Perfluoroalkyl sulfonates; significant new use rule. (EPA-HQ-OPPT-2005-0015-0040). https://www.regulations.gov/document/EPA-HQ-OPPT-2005-0015-0040.
U.S. EPA (U.S. Environmental Protection Agency). (2011). Recommended use of body weight 3/4 as the default method in derivation of the oral reference dose. (EPA100R110001). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/recommended-use-of-bw34.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2012a). Benchmark dose technical guidance [EPA Report]. (EPA100R12001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/benchmark-dose-technical-guidance.
U.S. EPA (U.S. Environmental Protection Agency). (2012b). Toxicological review of tetrahydrofuran. In support of summary information on the integrated risk information system (IRIS) (pp. 1–207). (EPA/635/R-11/006F). Washington, DC.
U.S. EPA (U.S. Environmental Protection Agency). (2013). Significant new uses: Perfluoroalkyl sulfonates and long-chain perfluoroalkyl carboxylate chemical substances. (EPA-HQ-OPPT-2012-0268-0034). https://www.regulations.gov/document/EPA-HQ-OPPT-2012-0268-0034.
U.S. EPA (U.S. Environmental Protection Agency). (2016a). Health effects support document for perfluorooctane sulfonate (PFOS) [EPA Report]. (EPA 822-R-16-002). Washington, DC: U.S. Environmental Protection Agency, Office of Water, Health and Ecological Criteria Division. https://www.epa.gov/sites/production/files/2016-05/documents/pfos_hesd_final_508.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2016b). Health effects support document for perfluorooctanoic acid (PFOA) [EPA Report]. (EPA 822-R-16-003). Washington, DC: U.S. Environmental Protection Agency, Office of Water, Health and Ecological Criteria Division. https://www.epa.gov/sites/production/files/2016-05/documents/pfoa_hesd_final-plain.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2016c). North American Free Trade Agreement (NAFTA) Technical Working Group on Pesticides (TWG) Developmental Neurotoxicity Study GuidanceDocument. (712B16001). https://nepis.epa.gov/exe/ZyPURL.cgi?Dockey=P100YH73.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2016d). The Third Unregulated Contaminant Monitoring Rule. Available online at https://www.epa.gov/dwucmr/third-unregulated-contaminant-monitoring-rule (accessed
U.S. EPA (U.S. Environmental Protection Agency). (2018a). Chemistry Dashboard. Washington, DC. Retrieved from https://comptox.epa.gov/dashboard
U.S. EPA (U.S. Environmental Protection Agency). (2018b). Human health toxicity values for perfluorobutane sulfonic acid (CASRN 375-73-5) and related compound potassium perfluorobutane sulfonate (CASRN 29420-49-3) (public comment draft). (EPA-823-R-18-307). Washington, DC.
U.S. EPA (U.S. Environmental Protection Agency). (2018c). ToxCast data pipeline R package. Retrieved from https://figshare.com/articles/GitHub_ToxCast_Data_Pipeline_R_Package/6062788
U.S. EPA (U.S. Environmental Protection Agency). (2018d). Toxic Release Inventory (TRI). Retrieved from https://www.epa.gov/enviro/tri-search
U.S. EPA (U.S. Environmental Protection Agency). (2019a). ChemView [Database]. Retrieved from https://chemview.epa.gov/chemview
U.S. EPA (U.S. Environmental Protection Agency). (2019b). Development of the Proposed Unregulated Contaminant Monitoring Rule for the Fifth Monitoring Cycle (UCMR 5): Public Meeting and Webinar Held July 16, 2019. (815A19001). https://nepis.epa.gov/exe/ZyPURL.cgi?Dockey=P100XWUH.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2019c). EPA’s per- and polyfluoroalkyl substances (PFAS) action plan [EPA Report]. (EPA 823R18004). Washington, DC. https://www.epa.gov/sites/production/files/2019-02/documents/pfas_action_plan_021319_508compliant_1.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2020). Significant new use rule: Long-chain perfluoroalkyl carboxylate and perfluoroalkyl sulfonate chemical substances. (EPA-HQ-OPPT-2013-0225-0232). https://www.regulations.gov/document/EPA-HQ-OPPT-2013-0225-0232.
U.S. EPA (U.S. Environmental Protection Agency). (2021a). Human health toxicity values for hexafluoropropylene oxide (HFPO) dimer acid and its ammonium salt (CASRN 13252-13-6 and CASRN 62037-80-3). Also known as “GenX chemicals.” Final report [EPA Report]. (EPA-822R-21-010). Washington, DC: U.S. Environmental Protection Agency, Office of Water.
U.S. EPA (U.S. Environmental Protection Agency). (2021b). Human health toxicity values for perfluorobutane sulfonic acid (CASRN 375-73-5) and related compound potassium perfluorobutane sulfonate (CASRN 29420-49-3) [EPA Report]. (EPA/600/R-20/345F). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=350888.
U.S. EPA (U.S. Environmental Protection Agency). (2022a). IRIS toxicological review of perfluorobutanoic acid (PFBA) and related salts. (EPA/635/R-22/277F).
U.S. EPA (U.S. Environmental Protection Agency). (2022b). IRIS toxicological review of perfluorobutanoic acid and related salts. (EPA/635/R-22/277Fa). https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0701tr.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2023a). Public comment draft toxicity assessment and proposed maximum contaminant level goal for perfluorooctane sulfonic acid (PFOS) in drinking water. (EPA/822/P-23/007). https://www.epa.gov/system/files/documents/2023-03/MAIN_Proposed%20MCLG%20for%20PFOS%20in%20Drinking%20Water_3.9.23_For%20Proposal_0.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2023b). Public comment draft: toxicity assessment and proposed maximum contaminant level goal for perfluorooctanoic acid (PFOA) in drinking water. (EPA/822/P-23/005). https://www.epa.gov/system/files/documents/2023-03/MAIN_Proposed%20MCLG%20for%20PFOA%20in%20Drinking%20Water_3.9.23_For%20Proposal.pdf.
Vansell, NR. (2022). Mechanisms by Which Inducers of Drug Metabolizing Enzymes Alter Thyroid Hormones in Rats. Drug Metab Dispos 50: 508–517. 10.1124/dmd.121.000498.35046065
Velarde, MC; Chan, AFO; Sajo, MEJ, V; Zakharevich, I; Melamed, J; Uy, GLB; Teves, JMY; Corachea, AJM; Valparaiso, AP; Macalindong, SS; Cabaluna, ND; Dofitas, RB; Giudice, LC; Gerona, RR. (2022). Elevated levels of perfluoroalkyl substances in breast cancer patients within the Greater Manila Area. Chemosphere 286 Pt 1: 131545. 10.1016/j.chemosphere.2021.131545.34293563
Venkatesan, AK; Halden, RU. (2014). Loss and in situ production of perfluoroalkyl chemicals in outdoor biosolids-soil mesocosms. Environ Res 132: 321–327. 10.1016/j.envres.2014.04.024.24834828
Vongphachan, V; Cassone, CG; Wu, DM; Chiu, SZ; Crump, D; Kennedy, SW. (2011). Effects of perfluoroalkyl compounds on mRNA expression levels of thyroid hormone-responsive genes in primary cultures of avian neuronal cells. Toxicol Sci 120: 392–402. 10.1093/toxsci/kfq395.21212296
Wang, J; Zeng, XW; Bloom, MS; Qian, Z; Hinyard, LJ; Belue, R; Lin, S; Wang, SQ; Tian, YP; Yang, M; Chu, C; Gurram, N; Hu, LW; Liu, KK; Yang, BY; Feng, D; Liu, RQ; Dong, GH. (2019). Renal function and isomers of perfluorooctanoate (PFOA) and perfluorooctanesulfonate (PFOS): Isomers of C8 Health Project in China. Chemosphere 218: 1042–1049. 10.1016/j.chemosphere.2018.11.191.30609483
Wang, Z; Cousins, IT; Scheringer, M; Buck, RC; Hungerbühler, K. (2014). Global emission inventories for C4-C14 perfluoroalkyl carboxylic acid (PFCA) homologues from 1951 to 2030, Part I: production and emissions from quantifiable sources [Review]. Environ Int 70: 62–75. 10.1016/j.envint.2014.04.013.24932785
Weaver, YM; Ehresman, DJ; Butenhoff, JL; Hagenbuch, B. (2010). Roles of rat renal organic anion transporters in transporting perfluorinated carboxylates with different chain lengths. Toxicol Sci 113: 305–314. 10.1093/toxsci/kfp275.19915082
Weiss, JM; Andersson, PL; Lamoree, MH; Leonards, PEG; van Leeuwen, SPJ; Hamers, T. (2009). Competitive Binding of Poly- and Perfluorinated Compounds to the Thyroid Hormone Transport Protein Transthyretin. Toxicol Sci 109: 206–216. 10.1093/toxsci/kfp055.19293372
Whalan, JE. (2015). A toxicologist’s guide to clinical pathology in animals: Hematology, clinical chemistry, urinalysis. Switzerland: Springer International Publishing. 10.1007/978-3-319-15853-2.
WHO (World Health Organization). (2022). Anaemia (nutrition landscape information system (NLIS). Available online at https://www.who.int/data/nutrition/nlis/info/anaemia (accessed
Wiesel, TN. (1982). The postnatal development of the visual cortex and the influence of environment [Review]. Biosci Rep 2: 351–377. 10.1007/bf01119299.7049262
Wolf, CJ; Rider, CV; Lau, C; Abbott, BD. (2014). Evaluating the additivity of perfluoroalkyl acids in binary combinations on peroxisome proliferator-activated receptor-α activation. Toxicology 316: 43–54. 10.1016/j.tox.2013.12.002.24374136
Wolf, CJ; Takacs, ML; Schmid, JE; Lau, C; Abbott, BD. (2008). Activation of mouse and human peroxisome proliferator-activated receptor alpha by perfluoroalkyl acids of different functional groups and chain lengths. Toxicol Sci 106: 162–171. 10.1093/toxsci/kfn166.18713766
Xiao, L; JianQing, Z; Wei, L; XiaoNa, L; Xin, Z; YouSheng, J; Jian, Z; YiHe, J. (2011). Serum levels of perfluorinated compounds in the general population in Shenzhen, China. Chin Sci Bull 56: 3092–3099. 10.1007/s11434-011-4616-7.
Yang, CH; Glover, KP; Han, X. (2009). Organic anion transporting polypeptide (Oatp) 1a1-mediated perfluorooctanoate transport and evidence for a renal reabsorption mechanism of Oatp1a1 in renal elimination of perfluorocarboxylates in rats. Toxicol Lett 190: 163–171. 10.1016/j.toxlet.2009.07.011.19616083
Yang, CH; Glover, KP; Han, X. (2010). Characterization of cellular uptake of perfluorooctanoate via organic anion-transporting polypeptide 1A2, organic anion transporter 4, and urate transporter 1 for their potential roles in mediating human renal reabsorption of perfluorocarboxylates. Toxicol Sci 117: 294–302. 10.1093/toxsci/kfq219.20639259
Yoo, H; Washington, JW; Jenkins, TM; Ellington, JJ. (2011). Quantitative determination of perfluorochemicals and fluorotelomer alcohols in plants from biosolid-amended fields using LC/MS/MS and GC/MS. Environ Sci Technol 45: 7985–7990. 10.1021/es102972m.21247105
Zeng, XW; Qian, Z; Emo, B; Vaughn, M; Bao, J; Qin, XD; Zhu, Y; Li, J; Lee, YL; Dong, GH. (2015). Association of polyfluoroalkyl chemical exposure with serum lipids in children. Sci Total Environ 512–513: 364–370. 10.1016/j.scitotenv.2015.01.042.
Zhang, S; Guo, X; Lu, S; He, J; Wu, Q; Liu, X; Han, Z; Xie, P. (2022). Perfluorohexanoic acid caused disruption of the hypothalamus-pituitary-thyroid axis in zebrafish larvae. Ecotoxicol Environ Saf 232: 113283. 10.1016/j.ecoenv.2022.113283.35131581
Zhang, T; Sun, H; Lin, Y; Qin, X; Zhang, Y; Geng, X; Kannan, K. (2013a). Distribution of poly- and perfluoroalkyl substances in matched samples from pregnant women and carbon chain length related maternal transfer. Environ Sci Technol 47: 7974–7981. 10.1021/es400937y.23777259
Zhang, T; Zhang, B; Bai, X; Yao, Y; Wang, L; Shu, Y; Kannan, K; Huang, X; Sun, H. (2019). Health status of elderly people living near e-waste recycling sites: association of e-waste dismantling activities with legacy perfluoroalkyl substances (PFASs). Environ Sci Technol Lett 6: 133–140. 10.1021/acs.estlett.9b00085.
Zhang, Y; Beesoon, S; Zhu, L; Martin, JW. (2013b). Biomonitoring of perfluoroalkyl acids in human urine and estimates of biological half-life. Environ Sci Technol 47: 10619–10627. 10.1021/es401905e.23980546
Zheng, G; Schreder, E; Dempsey, JC; Uding, N; Chu, V; Andres, G; Sathyanarayana, S; Salamova, A. (2021). Per- and Polyfluoroalkyl Substances (PFAS) in Breast Milk: Concerning Trends for Current-Use PFAS. Environ Sci Technol 55: 7510–7520. 10.1021/acs.est.0c06978.33982557
Zhou, Q; Deng, S; Yu, Q; Zhang, Q; Yu, G; Huang, J; He, H. (2010). Sorption of perfluorooctane sulfonate on organo-montmorillonites. Chemosphere 78: 688–694. 10.1016/j.chemosphere.2009.12.005.20042218
Zhou, Y; Bao, WW; Qian, ZM; Dee Geiger, S; Parrish, KL; Yang, BY; Lee, YL; Dong, GH. (2017). Perfluoroalkyl substance exposure and urine CC16 levels among asthmatics: A case-control study of children. Environ Res 159: 158–163. 10.1016/j.envres.2017.08.005.28802206
Zhou, Y; Hu, LW; Qian, ZM; Chang, JJ; King, C; Paul, G; Lin, S; Chen, PC; Lee, YL; Dong, GH. (2016). Association of perfluoroalkyl substances exposure with reproductive hormone levels in adolescents: By sex status. Environ Int 94: 189–195. 10.1016/j.envint.2016.05.018.27258660
Zoeller, RT; Tan, SW; Tyl, RW. (2007). General background on the hypothalamic-pituitary-thyroid (HPT) axis [Review]. Crit Rev Toxicol 37: 11–53. 10.1080/10408440601123446.17364704