# AUTHORS|CONTRIBUTORS|REVIEWERS

Assessment Team (Lead Authors)
Michelle M. Angrish (https://orcid.org/0000-0002-4956-4806), Ph.D. | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Laura Dishaw (https://orcid.org/0000-0003-1609-8922), Ph.D. | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Authors
J. Allen Davis (https://orcid.org/0000-0002-3238-3849), M.S.P.H. | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Jeffry L. Dean II, Ph.D. | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Andrew Kraft (https://orcid.org/0000-0003-3630-6741), Ph.D. | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Elizabeth G. Radke (https://orcid.org/0000-0002-2504-2405), Ph.D. | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Paul Schlosser (https://orcid.org/0000-0002-9699-9108), Ph.D. | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Yu-Sheng Lin (https://orcid.org/0000-0002-6813-7826), M.S. | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Shana White (https://orcid.org/0000-0001-9497-0849), Ph.D. | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Jay Zhao (https://orcid.org/0000-0001-7600-8840), Ph.D., M.P.H. | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Todd Zurlinden (https://orcid.org/0000-0003-1372-3913), Ph.D. | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Contributors
Xabier Arzuaga (https://orcid.org/0000-0002-7978-5431), Ph.D. | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Johanna Congleton, M.S.P.H., Ph.D. | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Ingrid L. Druwe (https://orcid.org/0000-0002-0591-0295), Ph.D. | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
J. Phillip Kaiser, Ph.D., DABT | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Elizabeth Oesterling Owens, Ph.D. | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Michele M. Taylor (https://orcid.org/0000-0001-5049-0499), Ph.D. | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Andre Weaver, Ph.D. | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Amina Wilkins, M.P.H. | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Michael Wright, Sc.D. | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Belinda Hawkins, Ph.D. | U.S. EPA/Office of Research and Development/Office of Science Advisor, Policy, and Engagement
Jason C. Lambert, Ph.D., DABT | U.S. EPA/Office of Research and Development/Center for Computational Toxicology and Exposure
Kelly Garcia, B.S.* | Oak Ridge Associated Universities (ORAU) Contractor; *No longer with U.S. EPA
Carolyn Gigot, B.A.* | Oak Ridge Associated Universities (ORAU) Contractor; *No longer with U.S. EPA
Andrew Greenhalgh, B.S.* | Oak Ridge Associated Universities (ORAU) Contractor; *No longer with U.S. EPA
Shahreen Hussain, B.S.* | Oak Ridge Associated Universities (ORAU) Contractor; *No longer with U.S. EPA
Brittany Schulz (https://orcid.org/0000-0002-3815-668X), B.S. | Oak Ridge Associated Universities (ORAU) Contractor; *No longer with U.S. EPA
Production Team
Maureen Johnson | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Ryan Jones | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Dahnish B. Shams | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Vicki M. Soto | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Jessica M. Soto Hernandez (https://orcid.org/0000-0003-2321-7889) | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Samuel Thacker | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Garland Waleko | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Production Team
Ashlei Williams | Former Oak Ridge Associated Universities (ORAU) Contractor
Executive Direction
Wayne Cascio | CPHEA Center Director
V. Kay Holt | CPHEA Deputy Center Director
Samantha Jones | CPHEA Associate Director
Kristina A. Thayer (https://orcid.org/0000-0002-3616-618X) | CPAD Division Director
Andrew D. Kraft (https://orcid.org/0000-0003-3630-6741) | IRIS PFAS Team Lead, CPAD Associate Division Director
Paul D. White | CPAD Senior Science Advisor
Ravi Subramaniam (https://orcid.org/0000-0001-5588-4120) | Acting CPAD Senior Science Advisor
Janice S. Lee (https://orcid.org/0000-0002-4331-8452) | CPHEA/CPAD/Toxic Effects Assessment (RTP) Branch Chief
Viktor Morozov | CPHEA/CPAD/Quantitative Assessment Branch Chief
Elizabeth G. Radke (https://orcid.org/0000-0002-2504-2405) | CPHEA/CPAD/Science Assessment Methods Branch Chief
Garland Waleko | Acting CPAD Toxic Effects Assessment (DC) Branch Chief
Review; CPAD Executive Review Committee
Janice S. Lee | CPHEA/CPAD/Toxic Effects Assessment (RTP) Branch Chief
Kristina A. Thayer | CPAD Division Director
Paul D. White | CPAD Senior Science Advisor
Alan Stern | NJDEP (retired), Contractor
Karen Hogan | CPHEA/CPAD/ Emeritus

## Agency Reviewers

This assessment was provided for review to scientists in EPA’s program and regional offices. Comments were submitted by:

- Office of Children’s Health Protection
- Office of Land and Emergency Management
- Office of Pollution Prevention and Toxics
- Office of Water
- Region 2, New York
- Region 8, Colorado

## Interagency Reviewers

This assessment was provided for review to other federal agencies and the Executive Office of the President (EOP). Comments were submitted by:

- Agency for Toxic Substances and Disease Registry
- Department of Defense
- Executive Office of the President
- Food and Drug Administration
- National Institute for Occupational Safety and Health
- National Institutes of Health
- National Toxicology Program
- United States Department of Agriculture