# 5 DERIVATION OF TOXICITY VALUES

## 5.1 HEALTH EFFECT CATEGORIES CONSIDERED (CANCER AND NONCANCER)

Multiple noncancer health effects were examined following oral PFHxA exposures. The evidence integration judgments are based primarily on five animal toxicological studies (NTP, 2018; Klaunig et al., 2015; Iwai and Hoberman, 2014; Chengelis et al., 2009b; Loveless et al., 2009). These studies were generally rated high confidence in outcome-specific study evaluations. Based on these studies, it was determined that the evidence indicates PFHxA likely causes hepatic, developmental, hematopoietic, and endocrine effects in humans given sufficient exposure conditions. These health effects were considered for derivation of toxicity values. The dose levels associated with these hazards are further characterized in Section 5.2.1.

For all other health effects (i.e., renal, male, and female reproductive, immune, and nervous system), the evidence is inadequate to assess potential health effects, thus these were not considered for derivation of toxicity values.

No studies of inhalation exposure were identified, thus an RfC was not estimated (see Section 5.2.2). Similarly, the evidence base related to potential carcinogenicity was determined to contain “inadequate information to assess carcinogenic potential”; therefore, no cancer toxicity values were estimated for any exposure route (see Section 5.3).

## 5.2 NONCANCER TOXICITY VALUES

A reference dose (RfD) is the daily oral exposure to the human population (including sensitive subpopulations) that is likely without appreciable risk of deleterious effects during a lifetime. In addition to developing an RfD designed to protect against lifetime exposure, a less-than-lifetime toxicity value (referred to as a “subchronic RfD”) is estimated. These subchronic toxicity values are presented as they might be useful for certain decision purposes (e.g., site-specific risk assessments with less-than-lifetime exposures). Both RfD and subchronic RfD derivations include organ/system-specific RfDs (osRfDs) associated with each health effect considered for point of departure (POD) derivation. Subsequent decisions related to dosimetric extrapolation, application of uncertainty factors, and confidence in toxicity values are discussed below.

As noted above, a reference concentration (RfC) or subchronic RfC could not be developed.

### 5.2.1 Oral Reference Dose (RfD) Derivation

#### Study Selection

The identified hazards relating to developmental, hepatic, hematopoietic, and endocrine effects were based on five high confidence animal studies that were considered for use in deriving an oral reference dose (RfD). The developmental studies Loveless et al. (2009) or Iwai and Hoberman (2014) were selected to support RfD derivation for developmental effects, given that endpoints observed from exposures during early lifestages are known to be sensitive for developmental effects (compared with exposures at later lifestages) and thus more appropriate for estimating potential effects of lifetime exposure. Both studies used rats or mice as the laboratory animal species and used vehicle-exposed controls. Animals were exposed to reagent-grade Na^+^PFHxA (reported as 100% pure) or NH_4_^+^PFHxA (reported as 93.4% pure; impurities not reported) via a human-relevant route (oral administration via gavage) and for a duration of exposure (GD 6−18) encompassing critical windows relevant to the developmental effects of interest.

In addition to the developmental studies, subchronic (Chengelis et al., 2009b; Loveless et al., 2009) and chronic (Klaunig et al., 2015) studies in rats were selected to support RfD derivation for hepatic and hematopoietic outcomes of PFHxA exposure. Animals were exposed to Na^+^PFHxA (reported as 100% pure) or PFHxA (reported as 98.1% pure) via oral administration and for a duration relevant for estimating potential effects of lifetime exposure (90 days or 2 years). For endocrine outcomes, endpoints were available from the same subchronic and chronic studies, however observations were null except for increased thyroid follicular cell hypertrophy from the 90-day study (Loveless et al., 2009) in males and females. However, the 90-day findings were only observed at the highest dose, were inconsistent with findings from the other 90-day and chronic study and lacked support for coherence from other findings. Also available in the PFHxA database is a short-term (i.e., 28-day) study of PFHxA exposure in rats (NTP, 2018) that was interpreted to provide critical information supporting information supporting thyroid hazard identification and included quantitative data useful for dose response analysis. Note that, as discussed below, when developing a lifetime reference value, chronic or subchronic studies (and studies of developmental exposure) are generally preferred over short-term or acute studies, so the (NTP, 2018) study was ultimately not considered for use in deriving candidate lifetime toxicity values.

For hepatic outcomes, a collection of adverse effects was found in rats, with PFHxA exposure resulting in increased liver weights (absolute and relative) in adult exposed animals (Chengelis et al., 2009b; Loveless et al., 2009), histopathological lesions (i.e., hepatocellular necrosis), and hypertrophy. Other hepatic findings (increased liver enzymes [i.e., ALT, AST, ALP]; increased peroxisomal beta oxidation; decreased total protein, albumin, and bilirubin; and mechanistic evidence indicating PPARα activation in humans and rodents at similar concentrations of PFHxA) supported the final evidence integration judgments for these endpoints and were critical for identifying adverse, human relevant endpoints for dose-response analysis (as discussed in Section 3.2.1). For the purposes of dose-response modeling, hepatic hypertrophy was considered a more sensitive effect (compared with other hepatic findings such as relative liver weight). Hepatocellular hypertrophy was observed in both sexes by Loveless et al. (2009), whereas Chengelis et al. (2009b) observed hypertrophy in the livers of male mice, not females.

For hematopoietic outcomes, a collection of adverse effects including decreased HGB and decreased RBCs, which were coherent with other correlative changes in other red blood cell indicators as discussed in Section 3.2.4, were observed in PFHxA exposed rats. The observed HGB and RBC findings were considered the most sensitive and specific compared to other hematological findings (e.g., blood proteins, hematocrit) and both advanced for POD derivation as there was no reason to choose one endpoint over the other. Hemoglobin decreases were considered similar in sensitivity to decreases in red blood cell counts and, while hemoglobin is used as an indicator of disease of the blood (i.e., anemia) (WHO, 2022), there was no reason to advance one endpoint over the other. Hematopoietic effects were observed in both sexes in the subchronic studies, whereas the only significant observation from the chronic study was in females, likely due to females receiving the highest dose administered in the study (Klaunig et al., 2015). As described in Section 3.2.4, quantitative hematology measures in rats after 52 weeks are likely less reliable due to increasing naturally occurring diseases that decrease sensitivity; thus, no hematopoietic data after 51 weeks were considered for POD derivation.

For developmental outcomes adverse effects were observed that included decreased F_1_ pup body weight and increased perinatal mortality after gestational exposure (Iwai and Hoberman, 2014; Loveless et al., 2009). Effects on F_1_ pup body weight were strongest during the early postnatal period so these timepoints were prioritized. Perinatal mortality (still birth and postnatal deaths from PND 0–21) showed a clear dose-response across two experimental cohorts with overlapping dose ranges. Data were pooled for dose-response analysis. Eye opening delays were also observed but were not advanced for POD derivation because the PFHxA doses causing these effects were higher than those that lead to pup body weight deficits and perinatal mortality.

For endocrine outcomes, adverse effects related to the thyroid consisted of decreased free and total T4 and T3 levels observed in exposed rats in the short-term study (NTP, 2018), and increased thyroid follicular hypertrophy in a subchronic study (Loveless et al., 2009). Decreased thyroid hormone levels are judged relevant to human health, given the many similarities in the production, regulation, and functioning of thyroid hormones between rodents and humans. In addition, rodents are more sensitive to increases in thyroid follicular hypertrophy that was observed in one subchronic study compared with null findings from all other studies at similar and higher PFHxA dose levels (including in a chronic study). Thus, changes in thyroid hormone levels are considered more relevant for deriving human health toxicity values and increased thyroid hypertrophy was not considered further for RfD derivation. Total T4 assay measurements are more reliable than those provided by the assays available to measure free T4 due to the very small quantity of unbound (i.e., ‘free’) T4 in circulation (Faix, 2013; Thienpont et al., 2013). For this reason, total, but not free, T4 was moved forward for POD and candidate value derivation.

A summary of endpoints considered for toxicity value derivation is presented in Table 5-1.

Table 5-1 Endpoints considered for dose-response modeling and derivation of points of departure

Endpoint | Study, endpoint confidence, exposure duration | Strain, species, sex | POD derivation^a^ | Rationale for deriving POD
Hepatic
Increased relative liver weight | Chengelis et al. (2009b); High confidence, Subchronic (90 d) | Crl:CD(SD) rat, both | No | Liver weights were considered a less sensitive and specific measure of toxicity than other available hepatic findings such as increased hepatocellular hypertrophy.
Increased relative liver weight | Loveless et al. (2009); High confidence, Subchronic (90 d) | Crl:CD(SD) rat, both | No | Liver weights were considered a less sensitive and specific measure of toxicity than other available hepatic findings such as increased hepatocellular hypertrophy.
Increased hepatocellular hypertrophy | Chengelis et al. (2009b); Low confidence, Subchronic (90 d) | Crl:CD(SD) rat, both | No | Endpoint considered adverse based on collection of hepatic findings (see Section 3.2.1) and a biologically plausible precursor event of more severe outcomes such as necrosis. Although male-specific effects were observed in Chengelis et al. (2009b), the evaluation of this outcome in this study was considered low confidence and therefore not advanced. Both sexes were affected in Loveless et al. (2009) and advanced.
Increased hepatocellular hypertrophy | Loveless et al. (2009); High confidence, Subchronic (90 d) | Crl:CD(SD) rat, both | Yes
Increased hepatocellular necrosis | Klaunig et al. (2015); High confidence, Chronic (104 w) | Crl:CD(SD) rat, female | Yes | Although significant effects were only observed at the highest dose in females, and largely in animals that died an unscheduled death, necrosis was advanced for further consideration as it represents a severe and specific indication of hepatic toxicity.
Hematopoietic
Decreased blood proteins (total protein and globulin) | Chengelis et al. (2009b); High confidence, Subchronic (90 d) | Crl:CD(SD) rat, both | No | Several hematologic endpoints are available and some (e.g., red blood cells and hemoglobin) are considered a more direct measure of hematopoietic effects than these markers.
Decreased blood proteins (total protein and globulin) | Loveless et al. (2009); High confidence, Subchronic (90 d) | Crl:CD(SD) rat, both | No | Several hematologic endpoints are available and some (e.g., red blood cells and hemoglobin) are considered a more direct measure of hematopoietic effects than these markers.
Decreased blood proteins (total protein and globulin) | Klaunig et al. (2015); High confidence, Chronic (51 w) | Crl:CD(SD) rat, both | No | Several hematologic endpoints are available and some (e.g., red blood cells and hemoglobin) are considered a more direct measure of hematopoietic effects than these markers.
Decreased hematocrit | Chengelis et al. (2009b); High confidence, Subchronic (90 d) | Crl:CD(SD) rat, both | No | Hematocrit is a measure of the percentage by volume of red blood cells in blood. The endpoint was considered a less direct measure of hematopoietic outcomes compared with other endpoints (e.g., red blood cells and hemoglobin) that were also available from the same studies.
Decreased hematocrit | Loveless et al. (2009); High confidence, Subchronic (90 d) | Crl:CD(SD) rat, both | No
Decreased hematocrit | Klaunig et al. (2015); High confidence, Chronic (51 wk) | Crl:CD(SD) rat, female | No
Decreased hemoglobin | Chengelis et al. (2009b); High confidence, Subchronic (90 d) | Crl:CD(SD) rat, both | Yes | The endpoint was considered a sensitive and specific adverse hematopoietic outcome (see Section 3.2.4). Male endpoints from the chronic study were mostly null and not advanced for POD derivation.
Decreased hemoglobin | Loveless et al. (2009); High confidence, Subchronic (90 d) | Crl:CD(SD) rat, both | Yes | The endpoint was considered a sensitive and specific adverse hematopoietic outcome (see Section 3.2.4). Male endpoints from the chronic study were mostly null and not advanced for POD derivation.
Decreased hemoglobin | Klaunig et al. (2015); High confidence, Chronic (51 wk) | Crl:CD(SD) rat, female | Yes | The endpoint was considered a sensitive and specific adverse hematopoietic outcome (see Section 3.2.4). Male endpoints from the chronic study were mostly null and not advanced for POD derivation.
Decreased hemoglobin | Klaunig et al. (2015); High confidence, Chronic (51 wk) | Crl:CD(SD) rat, male | No | The endpoint was considered a sensitive and specific adverse hematopoietic outcome (see Section 3.2.4). Male endpoints from the chronic study were mostly null and not advanced for POD derivation.
Decreased red blood cells | Chengelis et al. (2009b); High confidence, Subchronic (90 d) | Crl:CD(SD) rat, both | Yes | The endpoint was considered a biologically significant endpoints that is sensitive and specific for hematopoietic outcomes. There was no clear reason to advance one study over others.
Decreased red blood cells | Loveless et al. (2009); High confidence, Subchronic (90 d) | Crl:CD(SD) rat, both | Yes | The endpoint was considered a biologically significant endpoints that is sensitive and specific for hematopoietic outcomes. There was no clear reason to advance one study over others.
Decreased red blood cells | Klaunig et al. (2015); High confidence, Chronic, (51 wk) | Crl:CD(SD) rat, female | Yes | The endpoint was considered a biologically significant endpoints that is sensitive and specific for hematopoietic outcomes. There was no clear reason to advance one study over others.
Increased reticulocytes | Chengelis et al. (2009b); High confidence, Subchronic (90 d) | Crl:CD(SD) rat, female | No | Increases were considered to reflect a compensatory (secondary) response to decreased red blood cell parameters.
Increased reticulocytes | Loveless et al. (2009); High confidence, Subchronic (90 d) | Crl:CD(SD) rat, both | No | Increases were considered to reflect a compensatory (secondary) response to decreased red blood cell parameters.
Increased reticulocytes | Klaunig et al. (2015); High confidence, Chronic, (51 wk) | Crl:CD(SD) rat, both | No | Increases were considered to reflect a compensatory (secondary) response to decreased red blood cell parameters.
Developmental
Decreased, postnatal (F_1_) pup body weight | Loveless et al. (2009); High confidence, One-generation reproductive; measured on PND 0, 4, 7, 14, 21 | Crl:CD(SD) rat, F_1_ | Yes | Effects on body weight were strongest during the early postnatal period so these timepoints were prioritized.
Decreased, postnatal (F_1_) pup body weight | Iwai and Hoberman (2014); High confidence, Developmental (GD 6–18); measured on PND 0, 4, 7, 14, 21 | CD-1 mouse, F_1_ | Yes | Effects on body weight were strongest during the early postnatal period so these timepoints were prioritized.
Decreased, F_1_ fetal body weight | Loveless et al. (2009); High confidence, Develop-mental (GD 6–20); measured on GD 21 | Crl:CD(SD) rat, F_1_ | No | Statistically nonsignificant 9% decrease only at the highest dose.
Increased, perinatal mortality | Iwai and Hoberman (2014); High confidence, Developmental (GD 6–18); measured on PND 0–21, including stillbirths | CD-1 mouse, F_1_ | Yes | Perinatal mortality (still birth and postnatal deaths from PND 0–21) showed a clear dose-response across two experimental cohorts with overlapping dose ranges. These data were pooled for dose-response analysis.
Delayed eye opening | Iwai and Hoberman (2014); High confidence, Develop-mental (GD 6–18); measured on PND 10–17 | CD-1 mouse, F_1_ | No | Delays were observed at a dose that elicited body weight deficits and perinatal mortality.
Endocrine
Decreased thyroxine (T4), total | NTP (2018); High confidence, Short term (28 d) | Harlan Sprague-Dawley rat, male | Yes | Males showed statistically significant decreases in free and total T4 and T3 at all doses. No effects were observed in females. Total T4 was prioritized due to a clear dose response pattern across the tested exposure range and increased assay reliability (vs. free T4).
Decreased thyroxine (T4), total | NTP (2018); High confidence, Short term (28 d) | Harlan Sprague-Dawley rat, female | No
Decreased thyroxine, free (fT4) | NTP (2018); High confidence, Short term (28 d) | Harlan Sprague-Dawley rat, male | No
Decreased thyroxine, free (fT4) | NTP (2018); High confidence, Short term (28 d) | Harlan Sprague-Dawley rat, female | No
Decreased triiodothyronine (T3) | NTP (2018); High confidence, Short term (28 d) | Harlan Sprague-Dawley rat, male | No
Decreased triiodothyronine (T3) | NTP (2018); High confidence, Short term (28 d) | Harlan Sprague-Dawley rat, female | No
Increased Thyroid epithelial cell hypertrophy | Loveless et al. (2009); High confidence, Subchronic (90 d) | Crl:CD(SD) rat, both | No | Increased incidence in thyroid epithelial hypertrophy only observed in one subchronic study at the high dose (Loveless et al., 2009).
Increased Thyroid epithelial cell hypertrophy | Chengelis et al. (2009b); High confidence, Subchronic (90 d) | Crl:CD(SD) rat, both | No | Increased incidence in thyroid epithelial hypertrophy only observed in one subchronic study at the high dose (Loveless et al., 2009).
Increased Thyroid epithelial cell hypertrophy | Klaunig et al. (2015); High confidence, Chronic (104 w) | Crl:CD(SD) rat, both | No | Increased incidence in thyroid epithelial hypertrophy only observed in one subchronic study at the high dose (Loveless et al., 2009).
Increased Thyroid epithelial cell hypertrophy | NTP (2018); High confidence, Short term (28 d) | Harlan Sprague-Dawley, both | No | Increased incidence in thyroid epithelial hypertrophy only observed in one subchronic study at the high dose (Loveless et al., 2009).
Increased thyroid weight | NTP (2018); High confidence, Short term (28 d) | Harlan Sprague-Dawley, both | No | Treatment-related effects were limited to a single study that only qualitatively reported increased thyroid weight in high dose group females.
Increased thyroid weight | Loveless et al. (2009); High confidence, Subchronic (90 d) | Crl:CD(SD) rat, both | No | Treatment-related effects were limited to a single study that only qualitatively reported increased thyroid weight in high dose group females.
Increased thyroid weight | Chengelis et al. (2009b); High confidence, Subchronic (90 d) | Crl:CD(SD) rat, both | No | Treatment-related effects were limited to a single study that only qualitatively reported increased thyroid weight in high dose group females.

a See text for rationale for inclusion/exclusion from point-of-departure derivation.

#### Estimation or Selection of Points of Departure (PODs)

The outcomes determined most appropriate for quantifying the identified noncancer hazards and advanced for dose-response analysis (see Table 5-1) were modeled using approaches consistent with EPA’s Benchmark Dose (BMD) Technical Guidance document (U.S. EPA, 2012a). Specifically, the BMD and 95% lower confidence limit on the BMD (BMDL) were estimated using a benchmark response (BMR) to represent a minimal, biologically significant level of change. BMD modeling of continuous data was conducted using EPA’s Benchmark Dose Software (BMDS, Version 3.2).

Ideally, the selected BMR is based on data that support the biological relevance of the outcome being evaluated; however, in some cases there is no clear scientific understanding to support a biologically based BMR. In these instances, the BMD guidance provides some BMRs that can be applied to the data. For data drawn from toxicological studies, a suggested BMR of 1 standard deviation (SD) from the control mean for continuous data or a BMR of 10% extra risk (ER) for dichotomous data can be used to estimate the BMD and BMDL. The selection of these BMRs, as indicated in Table 5-2, is based on BMD guidance stating that in the absence of information regarding the level of change considered biologically significant, these BMRs can be used (U.S. EPA, 2012a). For effects on offspring body weights, a BMR of 5% relative deviation (RD) from the control mean is used for continuous data to account for effects occurring in a sensitive lifestage (U.S. EPA, 2012a).

Table 5-2 Benchmark response levels selected for BMD modeling of PFHxA health outcomes

Endpoint | BMR | Rationale
Hepatic effects
Hepatocellular hypertrophy | 10% ER | For dichotomous hepatic data, a 10% ER is generally considered a minimally biologically significant response level (U.S. EPA, 2012a).
Hepatocellular necrosis | 10% ER | For dichotomous hepatic data, a 10% ER is generally considered a minimally biologically significant response level (U.S. EPA, 2012a).
Developmental effects
Postnatal (F_1_) body weight | 5% RD | A 5% RD in markers of growth/development in gestational studies (e.g., fetal weight) has generally been considered a minimally biologically significant response level and has been used as the BMR for benchmark dose modeling in prior IRIS assessments (U.S. EPA, 2012b, 2004, 2003).
Offspring mortality | 1% ER | Although 5% ER is generally supported for developmental and reproductive outcomes (U.S. EPA, 2012a), a lower BMR of 1% ER was considered appropriate for modeling offspring mortality considering the severity of the frank effect.
Hematopoietic effects
Red blood cells | 1 SD | No biological information is readily available that allows for determining a minimally biological significant response for these outcomes. The BMD Technical Guidance (U.S. EPA, 2012a) recommends a BMR based on 1 SD in such a situation.
Hemoglobin | 1 SD
Endocrine effects
Total T4 | 1 SD | Evidence to support identification of a minimally biologically significant response for thyroid hormones is lacking in adult animals. In developing animals, there is a wide range in the level of response in thyroid hormones associated with neurodevelopmental effects (10%−25% for serum T4) in human and rodent studies (Gilbert et al., 2016; Gilbert, 2011; Haddow et al., 1999).; Given that the biological information is not sufficient to identify the BMR and the decreases in serum T4 (up to 73%) in male rats exceed these values, a 1 SD for continuous data was selected for this endpoint, consistent with EPAs Benchmark Dose Technical Guidance (U.S. EPA, 2012a).

An adequate fit is judged based on χ2 goodness-of-fit p-value (p > 0.1), magnitude of the scaled residuals in the vicinity of the BMR, and visual inspection of the model fit. In addition to these three criteria for judging adequacy of model fit, a determination is made as to whether the variance across dose groups is homogeneous. If a homogeneous variance model is deemed appropriate based on the statistical test provided by BMDS (i.e., Test 2), the final BMD results are estimated from a homogeneous variance model. If the test for homogeneity of variance is rejected (i.e., Test 2; p < 0.05), the model is run again while modeling the variance as a power function of the mean to account for this nonhomogeneous variance. If this nonhomogeneous variance model does not adequately fit the data (i.e., Test 3; p < 0.05), the data set is considered unsuitable for BMD modeling. Among all models providing adequate fit for a given endpoint, the benchmark dose lower confidence limit (BMDL) from the model with the lowest Akaike’s information criterion (AIC) was selected as a potential POD when BMDL values were sufficiently close (within 3-fold). Otherwise, the lowest BMDL was selected as a potential POD for each endpoint.

Where modeling was feasible, the estimated BMDLs were used as PODs. Further details, including the modeling output and graphical results for the model selected for each endpoint, can be found in Supplemental Information, Appendix B. The benchmark dose approach involving modeling to obtain the BMDL is preferred, but it involves modeling dose levels corresponding to BMR levels near the low end of the observable range of the data and is not always feasible. When data sets were not amenable to BMD modeling, no-observed-adverse-effect level (NOAEL) or lowest-observed-adverse-effect level (LOAEL) values were selected and used as the POD based on expert judgment, considering the study design features (e.g., severity and rarity of the outcome; biological significance, considering the magnitude of change at the NOAEL or LOAEL; statistical significance and power; exposure and outcome ascertainment methods).

For the study by Iwai and Hoberman (2014), the experiment was conducted in two phases. Except for differences in the dose levels, the design and conduct were the same across the two phases. Specifically, in addition to concurrent control groups for each phase, animals were exposed to 100, 350, or 500 mg/kg-day in Phase 1 and 7, 35 or 175 mg/kg-day in Phase 2. When possible, the two phases were combined for modeling to provide a more robust dose range. If the combined data set did not result in adequate model fit, the phases were modeled separately and the results for the individual phases were presented.

#### Approach for Animal-Human Extrapolation of PFHxA Dosimetry

The PFAS protocol (Appendix A) recommends the use of physiologically based pharmacokinetic (PBPK) models as the preferred approach for dosimetry extrapolation from animals to humans, while allowing for the consideration of data-informed extrapolations (such as the ratio of serum clearance values) for PFAS that lack a scientifically sound and sufficiently validated PBPK model. If chemical-specific information is not available, the protocol then recommends that doses be scaled allometrically using body weight (BW)^3/4^ methods. This hierarchy of recommended approaches for cross-species dosimetry extrapolation is consistent with EPA’s guidelines on using allometric scaling for deriving oral reference doses (U.S. EPA, 2011). This hierarchy preferentially prioritizes adjustments that result in reduced uncertainty in the dosimetric adjustments (i.e., preferring chemical-specific values to underpin adjustments versus use of default approaches).

As discussed in Section 3.1.5, no PBPK model is available for PFHxA in rats, mice, or monkeys. Although a PBPK model for humans was described by Fàbrega et al. (2015), it was not considered sufficiently reliable for use in an IRIS Toxicological Review.

There are, however, pharmacokinetic information available for PFHxA in relevant animal species (rats, mice, and monkeys) or humans that were useful for data-informed extrapolation approach for estimating the dosimetric adjustment factor (DAF) for PFHxA. Various PK analyses can be performed to extract meaningful information from PK data. Because PK data for various PFAS are available, including for PFBA (Chang et al., 2008), PFBS (Olsen et al., 2009), PFHxA (Dzierlenga et al., 2019), PFHxS (Sundström et al., 2012), PFNA (Tatum-Gibbs et al., 2011), and PFOA and PFOS (Kim et al., 2016b), that show a clear biphasic elimination pattern indicative of distinct distribution and elimination phases, EPA chose to use a two-compartment PK model, similar to the analysis of (Fujii et al., 2015). The EPA model is characterized by equation 5-1:

C ( t ) = A ⋅ exp ( − α ⋅ t ) + B ⋅ exp ( − β ⋅ t ) − flag_oral_ ⋅ ( A + B ) exp ( − k_a_ ⋅ t ) , (5-1)

where α and β are first-order rate constants (units of time^−1^) representing the rate of distribution and elimination, respectively, k_a_ is a rate constant (units of time^−1^) for oral absorption, and flag_oral_ is set to zero when analyzing intravenous dose data or one for oral data. Details of the model fitting are provided in Appendix B. The model assumes that oral bioavailability is 100%, consistent with PK data from Dzierlenga et al. (2019) and other studies and that internal dosimetry and elimination are linear with dose. This is implicitly a two-compartment PK model represented by the model, for which the rate of elimination corresponds to β. It is presumed that the total concentration from several consecutive doses would be obtained by simply adding the individual concentration curves, given the distinct dose times.

This PK model assumes the parameters are independent of time and dose. As discussed in the “Elimination” section, PK studies that measured tissue concentrations after multiple days of exposure are consistent with simple PK models parameterized from one-day exposure and support the assumption that the model parameters are independent of time. Although PK data at lower doses do not show any trend consistent with dose-dependence, data for the highest dose indicate that elimination can be reduced (Dzierlenga et al., 2019); the opposite of what is predicted based on the hypothesis of saturable resorption. While saturation of reabsorption transporters would lead to a decreased half-life at higher doses, there are also transporters responsible for elimination of PFAS to urine, such as Oat1 and Oat3, and saturation of these transporters could lead to an increase in observed half-life. A systematic deviation from the assumption of equal or more rapid clearance at higher doses has not been observed in the other relevant data (Iwabuchi et al., 2017; Gannon et al., 2011; Chengelis et al., 2009a). Further, because PFHxA is not metabolized, nonlinearity in its internal dose is not expected due to that mechanism. Parameter estimation, however, was performed both including and excluding the highest dose data. Had the resulting estimate of β been significantly different when the high-dose data were included, this would have indicated a dose dependence. The results of the alternative analyses did not indicate such a difference, however, leading to the conclusion that PFHxA PK is not dose dependent and that the assumption of nonvarying parameters in the PK model equation is appropriate. Further details are provided in Appendix C.

Given the fit of this model to a specific data set, the AUC from the time of exposure to infinity is:

AUC_inf_ = A / α + B / β − flag_oral_ ⋅ ( A + B ) / k_a_ (5-2)

AUC is the integral of the chemical concentration in blood or serum over time, with units of mass × time / volume (e.g., mg-hr/L), and is considered an appropriate measure of internal dose when the chemical has an accumulative effect over time.

By definition, the clearance (CL) of a compound is the effective volume of blood cleared of the compound per unit time (units of volume/time). Mathematically, given the PK model described above, CL = dose/AUC_inf_. If one assumes that risk increases in proportion to AUC, the ratio of clearance in animal to that in the human, CL_A_:CL_H_, can then be used to convert an oral dose-rate in animals (mg/kg-day) to a human equivalent dose (HED) rate. A similar approach using the ratio of the beta-phase half-lives can be used and is outlined in Appendix C, but that approach ignores differences in the absorption rate and alpha-phase distribution rate that impact AUC and is, therefore, considered to produce a more uncertain outcome. The relationship between the volume of distribution (Vd), CL and half-life (t_1/2_) is given by:

CL = ln ( 2 ) × Vd / T_1 / 2_ .

Hence: CL_A_ / CL_H_ = ( Vd_A_ / Vd_H_ ) / ( t_1 / 2 , A_ / t_1 / 2 , H_ ) .

So, if one assumes Vd_H_ = Vd_A_, as the EPA has done, then:

CL_A_ / CL_H_ = 1 / ( t_1 / 2 , A_ / t_1 / 2 , H_ ) ;

i.e., the clearance ratio is equal to one over the half-life ratio, so there is no quantitative difference between the two options for HED calculation in this case. However, if there were independent data to identify Vd_H_, the value might not be identical to Vd_rat_, in which case the clearance ratio would be different from the half-life ratio. Further, using the estimated clearance ratio makes the calculation more transparent because it requires an explicit statement of the assumption that Vd_H_ = Vd_rat_, while use of the ratio of half-lives makes this assumption implicitly, hiding it from consideration as a factor introducing uncertainty.

Therefore, the HED was explicitly calculated using the ratio of clearance values:

HED = ( CL_H_ / CL_A [ s ]_ ) × POD (5-3)

Given the PK model and definition of clearance above, the resulting HED is the dose that results in the same AUC in humans as is predicted in animals exposed at the POD, if one can obtain a value of CL_H_.

In the term CL_A[s]_, the [s] in the subscript refers to the sex-specific value available for animals but not humans in the case of PFHxA. Because there are sex-specific values (significant differences between males and females) in clearance among mice and rats, the CL values for female rodents would be used to extrapolate health effects in female rodents and the CL values for male rodents would be used to extrapolate male rodent health effects. This choice simply ensures that an observed effect in male rats, for example, is extrapolated using the expected internal dose for male rats. When endpoints from both male and female animals are analyzed (i.e., separate dose-response analyses are conducted for results in males vs. females) resulting in sex-specific PODs, the corresponding male and female human HEDs would be calculated, using (CL_H_/CL_A[s]_).

The volume of distribution in the beta phase (i.e., after the chemical has distributed into the body as a whole) given the two-compartment model above is:

V_d , β_ = CL / β = dose / [ β × ( A / α + B / β − flag_oral_ × ( A + B ) / k_a_ ) ] (5-4)

Except for the i.v. dose data from Dzierlenga et al. (2019), the V_d_ for rats for all other experiments and studies for male and female rats were between 0.9 and 1.7 L/kg and the averages for males and females were virtually indistinguishable: 1.37 and 1.35 L/kg, respectively. For the i.v. dose data from Dzierlenga et al. (2019), V_d, β_ was 5.2 L/kg in male rats and 18.7 L/kg in female rats. In contrast, V_d, β_ for the i.v. dose data from Chengelis et al. (2009a) was 0.93 L/kg for both male and female rats. Thus, excluding those specific i.v. experiments, V_d, β_ in rats does not appear to be sex specific and an overall average of 1.36 L/kg appears appropriate for that species.

For male and female mice, the corresponding V_d_ was 0.75 and 0.78 L/kg, respectively, based on data from Gannon et al. (2011), again not indicating a significant sex difference, although the value is somewhat lower than in rats.

For male and female monkeys, Chengelis et al. (2009a) reported V_d_ = 0.99 ± 0.58 L/kg and 0.47 ± 0.35 L/kg, respectively. Although these indicate a possible sex difference, only three animals of each sex were used and the estimated ranges (0.39–1.5 vs. 0.23–0.87 L/kg) significantly overlap. Hence, some caution in interpreting these data is required. The overall average V_d_ for monkeys, 0.73 L/kg, is similar to the value for mice, although also lower than the value in rats.

Because the volume of distribution (V_d_) has not been determined in humans, but an estimate for the human half-life (t_1/2_) is available, three options for estimating a clearance in humans can be considered, although this might be viewed as extreme for the purpose of predicting HED values. The observed t_1/2_ in humans is presumed to represent the beta or clearance phase, given the PFHxA study participant evaluation occurred over months after primary exposure to PFHxA had ended (Nilsson et al., 2010). Hence it is presumed that t_1/2_ = ln(2)/β. Rearranging the two equations, CL = V_d, β_ × β = V_d, β_ × ln(2)/t_1/2_. Three options were considered, as follows:

1) The V_d_ for humans is equal to that determined in the next closest species biologically, monkeys. This assumes the biological and biochemical factors that determine the tissue: serum concentration ratio and the relative proportion (fraction of BW) for various tissues is similar in humans and monkeys. This assumption presumes the relative binding of PFHxA in human serum relative to various other tissues in the body is like that in monkeys but leads to a conclusion that renal clearance in humans is significantly slower than in other species.
2) Use the clearance values estimated for mice, rats, and monkeys to estimate the clearance in humans via allometric scaling. The results for mice, rats, and monkeys in Table 5-3 show almost no trend with increasing species BW but can be fitted with a power function to obtain CL = 0.152·BW^−0.023^ (L/kg), assuming standard BW values of 0.03 and 0.25 kg for mice and rats, respectively, and the reported BW of monkeys used by Chengelis et al. (2009a). For a standard human BW of 80 kg, the resulting predicted clearance in humans is 0.137 L/hr-kg. If this is the actual clearance in humans, but t_1/2_ = 275 hr, human V_d, β_ = CL × t_1/2_/ln(2) = 54 L/kg. Note that human participants were exposed to PFHxA for months, which could have allowed them to accumulate a deep tissue dose, while the monkey PK study involved only a single i.v. administration. Thus, a much higher V_d_ might have been estimated in monkeys had they been subject to repeated doses.
3) The apparent human half-life estimated by EPA from the data of Nilsson et al. (2013) might be an artifact of significant ongoing exposure to PFHxA during the period of observation. Pérez et al. (2013) detected PFHxA levels in human tissues higher than other PFAS and other observational studies regularly detect PFHxA in human serum demonstrating widespread human exposure to the general population. Thus, there is no reason to believe the subjects of Nilsson et al. (2013) did not also have some level of ongoing exposure; the question is whether such exposure was significant relative to the body burden accumulated from exposure as ski-wax technicians. If the value of CL estimated in (2) (0.137 L/hr-kg) is an accurate prediction for humans and the V_d_ is equal to the average estimated for monkeys (0.73 L/kg), the half-life in humans should be t_1/2_ = ln(2) × V_d_ /CL =ln(2) × 0.73 (L/kg)/(0.137 L/hr-kg) = 3.7 hours. If this were the case, human serum levels would fall 99% in a single day, while the data of Nilsson et al. (2013) show that such a decline takes at least 2 months and, even after a day or two off work, a technician’s serum concentration would be near zero. Further, the serum concentrations reported Nilsson et al. (2013) do decline to near or below the limit of detection by late spring or early summer, indicating that other ongoing sources of exposure were not significant for that population. Thus, this third option seems extremely unlikely and was not evaluated further.

The two options for human CL estimated above are provided in Table 5-3.

Table 5-3 Summary of serum half-lives and estimated clearance for PFHxA

Species/sex | Study design | Elimination half-life (t_1/2_) (hr) | Clearance (CL) (L/hr-kg) | Volume of distribution (V_d_) (L/kg) | References/data sources
Rat, female | Oral and i.v. | 2.7 (0.5–11.2) | 0.383; (0.259–0.574)^a^ | 1.48; (0.27–4.42)^a^ | Dzierlenga et al. (2019); Chengelis et al. (2009a); Gannon et al. (2011)
Rat, male | Oral and i.v. | 5.4 (1.6–19.5) | 0.163; (0.112–0.228)^a^ | 1.31; (0.37–4.4)^a^ | Dzierlenga et al. (2019); Chengelis et al. (2009a); Iwabuchi et al. (2017); Gannon et al. (2011)
Mouse, female | Oral | 7.9 (2.8–23) | 0.206 (0.137–0.308)^a^ | 2.46 (0.82–6.82)^a^ | Gannon et al. (2011); Daikin Industries (2010)
Mouse, male | Oral | 10.6 (2.3–29) | 0.0894 (0.053–0.153)^a^ | 1.38; (0.31–3.73)^a^ | Gannon et al. (2011)
Monkey, female | i.v. | 2.4 | 0.136 | 0.474 ± 0.349^b^ | Chengelis et al. (2009a)
Monkey, male | i.v. | 5.3 | 0.122 | 0.989 ± 0.579^b^ | Chengelis et al. (2009a)
Human, male and female (data derived) | Ecological | 275 (145–510) | 1.84 × 10^−3^ ^c^; ((0.45 –7.35) × 10^−3^)^d^ | 0.73(0.33–1.45)^e^ | Nilsson et al. (2013)
Human, male and female (allometric) | NA | 275 | 0.137^f^ | 54^f^ | Nilsson et al. (2013)

a For each experiment (study/route/dose), a separate distribution of CL = dose/AUCinf and V_d_β = CL/β was generated. Median, 5th, and 95th percentiles of each distribution were calculated and are available on request. Results across experiments/dose levels were pooled, and the values presented here are statistics for the pooled results, 50th (5th–95th) percentiles for each species/sex.

b Reported mean ± SD from three male or female monkeys.

c CL = V_d_ × ln(2)/t_1/2_ with V_d_ assumed as the average of the estimated values for male and female monkeys and t_1/2_ estimated as described in Appendix C.2.

d As described in Section 3.1.4, the 90% CI for the elimination constant, k_e_ = ln(2)/t_1/2_, was combined with the estimated range of V_d_ to estimate an overall range of human CL.

e Upper and lower bounds of V_d_ for humans set to average value in rats (lower bound) and highest estimated individual value for monkeys (see Human Studies in Section 3.1.4), respectively.

f Human CL estimated by allometric scaling from values estimated for mice, rats, and monkeys; human t_1/2_ from EPA estimate (Section 3.1.4); human V_d_ = CL × t_1/2_/ln(2).

Thus, two alternative values of the DAF, CL_H_:CL_A[s]_—which is the ratio of clearance values—can be obtained (see Table 5-4). Even though there is no apparent difference in CL between men and women, the sex difference in rats and mice means that the internal dose in male rats at a given applied dose, for example, will be different from the internal dose in female rats given the same dose. Use of DAFs specific to the sex of the experimental animals in which an endpoint is observed is needed to account for this difference in dosimetry among laboratory animals. The HED for 10 mg/kg-day in male rats is expected to be different from the HED for 10 mg/kg-day in female rats because the internal dose in male rats will be higher than the internal dose in female rats at that dose.

Table 5-4 Two options for rat, mouse, and human clearance values and data-informed dosimetric adjustment factor

Sex | Species | Animal clearance (L/hr-kg)^a^ | Human clearance (L/hr-kg) | DAF (CL_H_:CL_A[s]_)
Male | Rat | 0.163 | 1.84 × 10^−3^ ^b^; ((0.45 –7.35) × 10^−3^)^c^; (mean, estimated rage, using preferred [data-driven] approach) | 1.1 × 10^−2^; (2.8 × 10^−3^ – 4.5 × 10^−2^)^d^
Male | Mouse | 0.0894 | 1.84 × 10^−3^ ^b^; ((0.45 –7.35) × 10^−3^)^c^; (mean, estimated rage, using preferred [data-driven] approach) | 2.1 × 10^−2^; (5.0 × 10^−3^ – 8.2 × 10^−2^)^d^
Female | Rat | 0.383 | 1.84 × 10^−3^ ^b^; ((0.45 –7.35) × 10^−3^)^c^; (mean, estimated rage, using preferred [data-driven] approach) | 4.8 × 10^−3^; (1.2 × 10^−3^ – 1.9 × 10^−2^)^d^
Female | Mouse | 0.206 | 1.84 × 10^−3^ ^b^; ((0.45 –7.35) × 10^−3^)^c^; (mean, estimated rage, using preferred [data-driven] approach) | 8.9 × 10^−3^; (2.2 × 10^−3^ – 3.6 × 10^−2^)^d^
Male | Rat | 0.163 | 0.137^e^; (alternative approach) | 0.84
Male | Mouse | 0.0894 | 0.137^e^; (alternative approach) | 1.5
Female | Rat | 0.383 | 0.137^e^; (alternative approach) | 0.36
Female | Mouse | 0.206 | 0.137^e^; (alternative approach) | 0.67

Shaded values were applied to derive the POD_HED_.

a Species/sex-specific CL values (see Appendix C).

b Calculated from mean human elimination constant, k_e_, obtained by Bayesian PK analysis and average volume of distribution for male and female monkeys (see Table 5-3).

c Calculated from 90% credible interval for the human elimination constant, k_e_, obtained by Bayesian PK analysis and the estimated range of volume of distribution for humans (see Table 5-3).

d DAF uncertainty calculated from estimated range of human clearance value.

e Calculated from allometric scaling of CL using results in Table 5-3.

To evaluate whether it is more reasonable to expect CL or V_d_ to be similar in humans as in experimental animals, values of CL were examined directly in humans for PFHxS, PFNA, and PFOA by Zhang et al. (2013b) and can be compared to those for experimental animals. By comparing human and rat clearance for a set of compounds from the same chemical family, for which data are available in both species, a “read across” can be done to evaluate the most likely case for PFHxA. Note that PFHxS has the same carbon chain length as PFHxA (C_6_) and while PFOA and PFNA have longer chains (C_8_ and C_9_ respectively) they are still much more chemically similar to PFHxA than any other compounds for which corresponding human data are available. Briefly, Zhang et al. (2013b) measured PFAS concentrations in serum and matched 24-hour urine samples to directly measure urinary clearance. To avoid the complicating issue of losses from menstrual blood, results for men and women over the age of 50 years are evaluated. Median urinary CL values reported by Zhang et al. (2013b) were 0.015, 0.094, and 0.19 mL/kg-day for PFHxS, PFNA, and total PFOA (all isomers), respectively.

Kim et al. (2016b) reported renal PFHxS clearance of 0.76 mL/kg-day in rats while Kim et al. (2016b) and Sundström et al. (2012) reported total clearance of 7–9 mL/kg-day. Sundström et al. (2012) also reported total clearance of PFHxS of 3–5 mL/kg-day in male mice and 1.3–1.9 mL/kg-day in monkeys. Thus, these results for PFHxS show significantly slower clearance in humans than in mice, rats, and monkeys.

Dzierlenga et al. (2019) evaluated the PK of PFOA (as well as PFHxA) in male rats and obtained clearance values of 9–16 mL/kg/d, depending on the dose and route. Thus, PFOA is also cleared much more rapidly in rats than humans.

The reported dose/AUC can be used to derive clearance values for PFNA from the results of Tatum-Gibbs et al. (2011). The estimated CL in rats is highly variable across the studies evaluated but ranged from 2 to 66 mL/kg-day in males and from 4 to 106 mL/kg-day in females (Tatum-Gibbs et al., 2011; Benskin et al., 2009; De Silva et al., 2009; Ohmori et al., 2003). CL in male and female mice reported by Tatum-Gibbs et al. (2011) ranged from 3 to 10 mL/kg-day. Although the wide range for rats indicates a degree of uncertainty, these results indicate that clearance in mice and rats is similar and much larger than the corresponding human value (0.094 mL/kg-day) (Zhang et al., 2013b).

Thus, three other PFAS, including one with the same carbon-chain length as PFHxA, have been shown to have much lower clearance in humans than rats. Data for PFDA were not discussed here since it is a C_10_ compound, but it also shows a similar rat-human difference in clearance. Hence, a read-across analysis suggests that option (1) above is more likely to be true.

The alternative, option (2) above, requires one to accept that the V_d_ in humans is roughly two orders of magnitude higher than in rats and monkeys, although the biochemical factors that determine serum-tissue partitioning are expected to be conserved across mammalian species, as described in the section above on distribution. Hence, option (2) seems highly unlikely.

Therefore, the top set of DAFs in Table 5-4—based on CL_human_ = 1.84 × 10^−3^ L/kg-hr—are the preferred set because they are consistent with data for other PFAS, and the reasonable expectation, based on data from multiple chemicals, is the volume of distribution in humans does not substantially differ from that in experimental animals.

Representative calculations of the HED for considered health effects follow, using the POD of 20 mg/kg-day for postnatal (F_1_) body weight at PND 0 (Loveless et al., 2009) as an example and the female rat DAF of 4.8 × 10^−3^, based on clearance:

H E D = H E D = P O D ( (m g)/(k g - d a y) ) × D A F 20 ( (m g)/(k g - d a y) ) × 4.8 × 10^− 3^ = 0.096 ( (m g)/(k g - d a y) ) (5-5)

In general, clearance captures the overall relationship between exposure and internal dose, specifically the average concentration of a substance in serum, while the half-life does not. Use of half-life makes an intrinsic assumption that V_d_ is the same in the test species as in humans. There is a significant difference between rats and monkeys, which leads to the expectation of a difference between rats and humans (see Table 5-3).

HED based on clearance incorporates the observed differences in V_d_ among mice, rats, and primates, and is therefore, the preferred approach for dosimetry extrapolation from animals to humans.

##### Uncertainty of Animal-human extrapolation of PFHxA dosimetry

Although the variability between, and even within, some data sets for rats (~4-fold for males and ~6-fold for females between the lowest and highest mean clearance values) is large, the number of studies provides confidence in the estimated average clearance values for both male and female rats, which is reflected by the modest 90% CI for rat CL in Table 5-3.

Only one PK study is available for mice, although with two dose levels (Gannon et al., 2011). Further, the data for the 100 mg/kg dose approach a plateau, as if clearance stopped when the concentration was around 0.5 µg/g, although such a plateau was not observed for the 2 mg/kg data. EPA concluded that the data, which used ^14^C labeling, were not correctly adjusted for the background signal or LOD. EPA was able to analyze the two dose levels for male and female mice successfully, however, by focusing on the data above the concentration at which the plateau occurred. Because the data from Gannon et al. (2011) for rats is near the middle of the range for other rat studies and the methods described otherwise are appropriate, it is presumed that this study has good quality results, except for the LOD correction of this dose in mice, is presumed. Therefore, some uncertainty remains with the clearance value obtained for mice from this study.

The PK study of Chengelis et al. (2009a) is considered high quality, but the results for monkeys used only three males and three females.

Uncertainty in the application of the DAF based on clearance remains, given that neither V_d_ nor CL were measured or determined in humans. To estimate CL in humans, the human V_d_ was assumed equal to the average value estimated in male and female monkeys, which seems less uncertain given the data and analyses described above. The V_d_ of male and female mice was assumed the same as in male and female rats, respectively. Because the difference in V_d_ between male and female rats was small, using these sex-specific values for mice will give similar results to using an average.

One alternative approach to using clearance in mice or rats to estimate the average blood concentrations in those species for each bioassay might be to use the measured serum concentrations from toxicological studies as BMD modeling inputs and then the estimated human clearance value to calculate the HED. Three of the four studies being evaluated, however, did not measure PFHxA serum concentrations (Klaunig et al., 2015; Iwai and Hoberman, 2014; Chengelis et al., 2009b; Loveless et al., 2009). Although Iwai and Hoberman (2014) attempted to measure serum concentrations in mice, all serum measurements were below the LOQ. Therefore, this alternative approach cannot be applied in evaluating these dose-response data.

There is uncertainty in the estimated human clearance because the V_d_ had to be extrapolated from animals (nonhuman primates) and the limited human PK data from only eight individuals with noncontrolled exposures. As discussed in Section 3.1.2, the distribution of PFHxA between serum and various tissues is determined by biochemical parameters such as the concentrations of various binding proteins and the affinity of PFHxA for those proteins, that are largely conserved across mammalian species. However, V_d_ values estimated for animals ranged between 0.33 L/kg in rats (Section 3.1.2) to 1.54 L/kg in one of six monkeys studied (Chengelis et al., 2009a), so uncertainty in the human V_d_ is presumed to be about 4.7-fold. Together with the estimated uncertainty in the human first-order elimination constant for which the 90% credible interval ranges 3.5-fold, an overall range of uncertainty in the human clearance of 16-fold (± 4-fold) was estimated (see Section 3.1.4 Pharmacokinetics-Elimination-Human Studies).

##### Application of Animal-Human Extrapolation for PFHxA Dosimetry

Table 5-5 presents the estimated POD_HED_ (mg/kg-day) values for the hepatic, developmental, and hematopoietic toxicity endpoints considered for RfD derivation based on the endpoint selection justification described above and in Table 5-1 and preferred DAF values presented in Table 5-4.

The last column in Table 5-5 includes normalization from the ammonium salt to the free acid using a molecular weight conversion [MW free acid/MW ammonium salt = 314/331 = 0.949 (Iwai and Hoberman, 2014)] and sodium salt to free acid [MW free acid/MW sodium salt = 314/336 = 0.935 (Loveless et al., 2009)]. The POD_HED_ for postnatal (F_1_) body weights used the female HED, as exposures were to the dams and assumed equal clearance in a developing offspring as an adult.

The free acid of PFHxA is calculated using the ratio of molecular weights, as follows:

P F H x A ( f r e e a c i d ) = ( (M W f r e e a c i d)/(M W a m m o n i u m s a l t) ) = ( (314)/(331) ) = 0.949 P F H x A ( f r e e a c i d ) = ( (M W f r e e a c i d)/(M W s o d i u m s a l t) ) = ( (314)/(336) ) = 0.935 (5-6)

Table 5-5 PODs considered for the derivation of the RfD

Endpoint | Study/confidence | Species, strain (sex) | POD type/model | POD (mg/kg-d) | POD_HED_ PFHxA^a^ (mg/kg-d)
Hepatic effects
↑Hepatocellular hypertrophy | Loveless et al. (2009); High confidence; Subchronic (90 d) | Rat, Crl:CD(SD) (male) | BMDL10ER; Multistage 1 NCV | 10.66 | 0.11^c^
↑Hepatocellular hypertrophy | Loveless et al. (2009); High confidence; Subchronic (90 d) | Rat, Crl:CD(SD) (female) | NOAEL^b^; (0% response) | 100 | 0.45^c^
↑Hepatocellular necrosis | Klaunig et al. (2015); High confidence; Chronic (104 w) | Rat, Crl:CD(SD) (female) | NOAEL^b^; (5% response vs. 3.3% in controls) | 30 | 0.14
Hematopoietic effects
↓Hemoglobin | Klaunig et al. (2015); High confidence; Chronic (51 w) | Rat, Crl:CD(SD) (female) | BMDL_1SD_; Linear CV | 122.77 | 0.59
↓Hemoglobin | Chengelis et al. (2009b); High confidence; Subchronic (90 d) | Rat, Crl:CD(SD) (male) | NOAEL^d^; (7% decrease) | 50 | 0.55
↓Hemoglobin | Chengelis et al. (2009b); High confidence; Subchronic (90 d) | Rat, Crl:CD(SD) (female) | NOAEL^d^; (3% decrease) | 50 | 0.24
↓Hemoglobin | Loveless et al. (2009); High confidence; Subchronic (90 d) | Rat, Crl:CD(SD) (male) | NOAEL^d^; (6% decrease) | 20 | 0.21^c^
↓Hemoglobin | Loveless et al. (2009); High confidence; Subchronic (90 d) | Rat, Crl:CD(SD) (female) | BMDL_1SD_; Polynomial 3 CV | 127.61 | 0.57^c^
↓Red blood cells | Klaunig et al. (2015); High confidence; Chronic (51 w) | Rat, Crl:CD(SD) (male) | NOAEL^b^; (4% decrease) | 100 | 1.21
↓Red blood cells | Klaunig et al. (2015); High confidence; Chronic (51 w) | Rat, Crl:CD(SD) (female) | BMDL_1SD_; Linear CV | 109.15 | 0.52
↓Red blood cells | Chengelis et al. (2009b); High confidence; Subchronic (90 d) | Rat, Crl:CD(SD) (male) | NOAEL^d^; (no change) | 50 | 0.55
↓Red blood cells | Chengelis et al. (2009b); High confidence; Subchronic (90 d) | Rat, Crl:CD(SD) (female) | BMDL_1SD_; Exponential 5 CV | 16.32 | 0.078
↓Red blood cells | Loveless et al. (2009); High confidence; Subchronic (90 d) | Rat, Crl:CD(SD) (male) | BMDL_1SD_; Linear NCV | 44.57 | 0.46^c^
↓Red blood cells | Loveless et al. (2009); High confidence; Subchronic (90 d) | Rat, Crl:CD(SD) (female) | BMDL_1SD_; Linear CV | 112.36 | 0.50^c^
Developmental effects
↓Postnatal (F_1_) body weight, PND 0 | Loveless et al. (2009); High confidence | Rat, Crl:CD(SD), F_1_ (combined) | BMDL_5RD_; Hill | 10.62 | 0.048^c^
↓Postnatal (F_1_) body weight, PND 0 | Iwai and Hoberman (2014); High confidence | Mouse, CD-1, F_1_ (combined) | BMDL_5RD_; Polynomial 3 CV; Phase 2 | 80.06 | 0.68^e^
↓Postnatal (F_1_) body weight, PND 4 | Iwai and Hoberman (2014); High confidence | Mouse, CD-1, F_1_ (combined) | BMDL_5RD_; Exponential-M5; Phase 1 and 2; Polynomial 3 CV; Phase 2 | 102.94; 89.79 | 0.87^e^; 0.76^e^
↑Perinatal (F_1_) mortality (PND 0–21, including stillbirths) | Iwai and Hoberman (2014); High confidence | Mouse, CD-1, F_1_ (combined) | BMDL_1E1R0_; NLogistic; Phase 2 | 24.77 | 0.21^e^
Endocrine effects
↓Total T4 | NTP (2018); High confidence; Short term (28 d) | Rat, Harlan Sprague-Dawley (male) | BMDL_1SD_; Hill CV | 25.97 | 0.29

CV = constant variance; NCV = nonconstant variance; SD = standard deviation.

a HED calculations based on the DAF, the ratio of human and animal clearance values (see Table 5-4). DAF values for female rats and female mice were used for the respective developmental effects on combined male and female pups of each species. POD_HED_ based on PFHxA free acid.

b Response only at high dose with responses far above BMR level, data not modeled.

c POD_HED_ multiplied by normalization factor to convert from sodium salt to free acid (MW free acid/MW sodium salt = 314/336 = 0.935).

d No models provided adequate fit; therefore, a NOAEL approach was selected.

e POD_HED_ multiplied by normalization factor to convert from ammonium salt to the free acid (MW free acid/MW ammonium salt = 314/331 = 0.949).

#### Derivation of Candidate Toxicity Values for the RfD

As discussed below, the subchronic, chronic, developmental, and short-term studies for hepatic, hematopoietic, developmental, and endocrine effects after PFHxA exposure were considered for use in deriving candidate toxicity values for the RfD. The PODs presented in Table 5-5 were considered and specific PODs were advanced for candidate toxicity value derivation over others within each health outcome category based on the confidence in the study, endpoint sensitivity and specificity, the POD_HED_, and other considerations including uncertainty (see Table 5-6), as discussed below. The candidate lifetime toxicity values are presented in Table 5-7.

For hepatic outcomes, candidate toxicity values for both increased hepatocellular hypertrophy and necrosis were derived. From the PODs for hepatocellular hypertrophy (Loveless et al., 2009), the POD for male rats was selected was selected over the POD for female rats as the POD_HED_ from males was several-fold lower. Although. Although increased hepatocellular hypertrophy was considered as likely to be precursor event of more severe outcomes such as necrosis (which might warrant deprioritizing necrosis), a candidate toxicity value for necrosis was also derived as both studies were of high confidence and the POD_HEDs_ did not notably differ.

For hematopoietic outcomes, data on RBCs and HGB from three high confidence studies were advanced for estimation of POD_HEDs_. Of those, the lowest POD_HED_, by a large margin, was for decreased RBCs in female rats from the high confidence subchronic study (Chengelis et al., 2009b) (POD_HED_ = 0.078 mg/kg-d). A candidate value for this POD was derived. Given the sensitivity of this POD over other PODs from the two subchronic studies and no clear reason to advance the other PODs (e.g., both studies were of high confidence and RBCs and HGB were interpreted to have similar sensitivity and specificity), none of the other PODs for RBCs or HGB from the subchronic studies were used to calculate candidate values. However, some caution in this POD is carried forward to candidate value derivation as the unadjusted POD was far below the observed NOAEL (50 mg/kg-d), suggesting that variability in the data may be a drive the candidate value lower. The subchronic POD_HED_ of 0.078 mg/kg-d (Chengelis et al., 2009b) was also 7-fold lower than the RBC finding available from the chronic study observed in the same sex, species, dose, and the magnitude of change in the response at 200 mg/kg-d was also similar (~8% decrease RBC). Although both subchronic and chronic exposure designs and study durations include the life cycle of a red blood cell (~60 days in rats), the subchronic study duration design may miss longer term effects on RBC regeneration. Therefore, although the POD_HED_ was less sensitive, the chronic POD for RBCs was also advanced for candidate toxicity value derivation.

For developmental outcomes, the high confidence finding of decreased postnatal (F_1_) body weight in rats at PND 0 had the lowest POD_HED_ of 0.048 mg/kg-d (Loveless et al., 2009). This was 4-fold lower than the next lowest POD_HED_ for increased perinatal mortality in mice (Iwai and Hoberman, 2014), and considerably lower than POD_HEDs_ for offspring body weight decreases in mice. Ultimately, given the large difference in PODs for body weight changes, the PODs in mice were not advanced and only a candidate toxicity value for decreased postnatal (F_1_) body weight in rats was derived. Because derived. Because changes in fetal body weight are less severe than fetal mortality and the POD_HED_ for the fetal body weight change in rats was only 4-fold more sensitive to PFHxA exposure than the POD_HED_ for offspring mortality in mice and therefore a candidate toxicity value was also derived for the increases in perinatal mortality in mice (Iwai and Hoberman, 2014).

For endocrine effects, the available POD was limited to thyroid hormone data from a short-term study in rats (NTP, 2018). Consistent with EPA’s A Review of the Reference Dose and Reference Concentration Processes (U.S. EPA, 2002c) and for the purposes of this assessment, a lifetime toxicity value is not supported given the high degree of uncertainty when using PODs from a short-term study to protect against effects of exposure for a lifetime. The general lack of long-term or developmental studies of endocrine effects introduces uncertainty, as discussed below.

Under EPA’s A Review of the Reference Dose and Reference Concentration Processes (U.S. EPA, 2002c) and Methods for Derivation of Inhalation Reference Concentrations and Application of Inhalation Dosimetry (U.S. EPA, 1994), five possible areas of uncertainty and variability were considered in deriving the candidate toxicity values for PFHxA. An explanation of these five possible areas of uncertainty and variability and the UF values assigned to each of the of the POD_HED_ values selected for use in deriving candidate toxicity values, as well as the rationales for these decisions are listed in Table 5-6.

Table 5-6 Uncertainty factors for the development of the RfD for PFHxA

UF | Value | Justification
UF_A_ | 3 | As described in EPA’s A Review of the Reference Dose and Reference Concentration Processes (U.S. EPA, 2002c), the interspecies uncertainty factor (UF_A_) is applied to account for extrapolation of animal data to humans. A UF_A_ of 3 is applied to account for uncertainty in characterizing the PK and pharmacodynamic differences between species (i.e., from rats or mice to humans) following oral PFHxA exposure. Some aspects of the cross-species extrapolation of PK processes have been accounted for by calculating an HED through application of a DAF based on animal and human clearance; however, residual uncertainty related to potential pharmacodynamic differences remains. Typically, a threefold UF is applied for this uncertainty in the absence of chemical-specific information. This is the case for the hepatic, hematopoietic, and developmental effects of PFHxA.
UF_H_ | 10 | A UF_H_ of 10 is applied for interindividual variability in humans in the absence of quantitative information on potential differences in PK and pharmacodynamics relating to PFHxA exposure in humans.
UF_S_ | 1 (developmental; hepatic and hematopoietic [chronic study]) | A UF_S_ of 1 is applied to the developmental endpoint from the one-generation reproductive study by Loveless et al. (2009) and developmental study by Iwai and Hoberman (2014). The developmental period is recognized as a susceptible lifestage and exposure designs capturing sensitive developmental windows (e.g., gestation) are more relevant for the induction of developmental effects than lifetime exposures (U.S. EPA, 1991). Although effects on body weights are not unique to development, the current evidence for PFHxA suggests this is a sensitive lifestage for body weight effects of PFHxA exposure based on effects being measured at lower doses than adults.; A UF_S_ of 1 is also applied to hematopoietic (i.e., decreased RBC) and hepatic (i.e., necrosis) endpoints in the chronic study (Klaunig et al., 2015) as the 51 wks of daily exposure is considered sufficiently representative of exposure for the rodents’ lifetime and the incidence or severity of these outcomes is not anticipated to increase with longer exposure duration.
UF_S_ | 3 (hepatic and hematopoietic [subchronic study]) | A UF_S_ of 3 is applied to hepatocellular hypertrophy for the purpose of deriving a lifetime RfD. Although the endpoint was derived from a 90-d subchronic study (Loveless et al., 2009), which would typically warrant application of a UF_S_ = 10, there are some other sparse data that mitigate this uncertainty, to an extent. Specifically, significant hepatocellular hypertrophy was not observed in the chronic study in male or female rats (Klaunig et al., 2015). However, a UF_S_ = 1 was not applied as the evidence supports a pathway where hepatocellular hypertrophy is an adverse event leading to more severe outcomes with longer exposure durations, such as the necrosis that was observed in female rats in the chronic study. Additionally, the highest dose levels used in the chronic study were at or below the LOAEL for this effect in the available subchronic studies (see Section 3.2.1). Thus, some uncertainty remains and a UF_S_ of 3 is applied.; A UF_S_ of 3 is applied to the hematopoietic endpoint (i.e., decreased RBCs) from the 90-d subchronic study (Chengelis et al., 2009b). Specifically, a UF_S_ lower than 10 was warranted as more significant effects on RBCs were not observed after chronic exposure at the same PFHxA doses (RBCs decreases of the same magnitude were observed at matched doses and sexes across exposure durations see Section 3.2.4); however, uncertainty remains when considering the doses tested in the chronic as compared to the subchronic study. Further, the subchronic study may poorly predict a chronic exposure setting across multiple RBC life cycles (one cycle is ~60 d), which could reflect cumulative effects as greater proportions of RBCs across stages are affected, or possibly even reduced effects (compensatory responses) warranting a UF_S_ higher than 1. Thus, a UF_S_ of 3 was applied.
UF_L_ | 1 | A UF_L_ of 1 is applied for LOAEL-to-NOAEL extrapolation when the POD is a BMDL or a NOAEL.
UF_D_ | 3 | The database uncertainty factor (UF_D_) is applied to account for the potential of deriving an under-protective reference value as a result of incomplete characterization of a chemical’s toxicity (U.S. EPA, 2002c). For PFHxA, a UFD of 3 was selected to account for deficiencies and uncertainties in the database. Although not large, the available evidence base spans a number medium and high confidence studies in laboratory animals, including several short-term studies, two subchronic studies, and one chronic study in Sprague-Dawley rats, as well as developmental/reproductive studies in Sprague-Dawley rats and Crl:CD1 mice. Limitations in the database, as described in U.S. EPA (2002c) were used as the basis for a UF_D_ = 3. These limitations included a lack of informative human studies for most outcomes; subchronic or chronic toxicity studies in more than one species; studies of potential multigenerational effects; effects; developmental neurotoxicity studies; and thyroid toxicity studies after PFHxA exposure during development or after long-term exposure.
UF_C_ | See Table 5-7 and Table 5-11 | Composite uncertainty factor = UF_A_ × UF_H_ × UF_S_ × UF_L_ × UF_D_.

UF_A_ = interspecies uncertainty factor, UF_H_ = interindividual variability in humans uncertainty factor, UF_s_ = extrapolating from subchronic to chronic uncertainty factor, UF_L_ = LOAEL-to-NOAEL extrapolation uncertainty factor, UF_D_ = database uncertainty factor.

The uncertainty factors described in Table 5-6 were applied and the resulting candidate values for use in estimating an RfD for lifetime exposure are shown in Table 5-7.

Table 5-7 Candidate values for PFHxA

Endpoint/study/confidence | Species, strain (sex) | POD_HED_ PFHxA^a^ (mg/kg-d) | UF_A_ | UF_H_ | UF_S_ | UF_L_ | UF_D_ | UF_C_ | Candidate value PFHxA (mg/kg-d) | Candidate value PFHxA-Na^b^ (mg/kg-d) | Candidate value PFHxA-NH_4_^b^ (mg/kg-d)
Hepatic effects
↑Hepatocellular hypertrophy, 90 d; Loveless et al. (2009); High confidence | Rat, Crl:CD(SD) (male) | 0.11 | 3 | 10 | 3 | 1 | 3 | 300 | 4 × 10^4^ | 4 × 10^−4^ | 4 × 10^−4^
↑Hepatocellular necrosis; 2 y; Klaunig et al. (2015); High confidence | Rat, Crl:CD(SD) (female) | 0.144 | 3 | 10 | 1 | 1 | 3 | 300 | 5 × 10^−4^ | 5 × 10^−4^ | 5 × 10^−4^
Hematopoietic effects
↓Red blood cells, 51 wks; Klaunig et al. (2015); High confidence | Rat, Crl:CD(SD) (female) | 0.52 | 3 | 10 | 1 | 1 | 3 | 100 | 5 × 10^−3^ | 6 × 10^−3^ | 5 × 10^−3^
↓Red blood cells 90 d; Chengelis et al. (2009b); High confidence | Rat, Crl:CD(SD) (male) | 0.078 | 3 | 10 | 3 | 1 | 3 | 300 | 3 × 10^−4^ | 3 × 10^−4^ | 3 × 10^−4^
Developmental effects
↓F_1_ body weight, PND 0; Loveless et al. (2009); High confidence | Rat, Sprague-Dawley, F_1_ (combined) | 0.048 | 3 | 10 | 1 | 1 | 3 | 100 | 5 × 10^−4^ | 5 × 10^−4^ | 5 × 10^−4^
↑Perinatal (F_1_) mortality (PND 0–21, including stillbirths); Iwai and Hoberman (2014); High confidence | Mouse, CD-1, F1 (combined) | 0.21 | 3 | 10 | 1 | 1 | 3 | 100 | 2 × 10^−3^ | 2 × 10^−3^ | 2 × 10^−3^

a HED calculations based on DAF, the ratio of human and animal clearance values (see Table 5-4). DAF values for female rats and female mice were used for the respective developmental effects on combined male and female pups of each species.

b To calculate candidate values for salts of PFHxA, multiply the candidate value of interest by the ratio of molecular weights of the free acid and the salt. For example, for the sodium salt of PFHxA, the candidate value would be calculated by multiplying the free acid candidate value by 1.070 (MW free acid/MW sodium salt = 336/314 = 1.070). This same conversion can be applied to other salts of PFHxA, such as the ammonium salt.

#### Selection of Lifetime Toxicity Value(s)

##### Selection of Organ- or System-Specific RfDs

Organ/system-specific (os)RfDs associated with each health effect are presented in Table 5-8 as they could be useful for certain decision purposes (i.e., site-specific risk assessments). The rationale for and application of osRfD are described in the PFAS Protocol, Appendix A. Confidence in each osRfD is described in Table 5-8 and is based on several factors, including confidence in the study, the evidence base supporting the hazard, and quantitative estimate for each osRfD.

The candidate toxicity value of 4 × 10^−4^ mg/kg-d PFHxA for hepatocellular hypertrophy was selected as the hepatic osRfD. Considering that hepatocellular hypertrophy likely precedes necrosis and is a slightly more sensitive endpoint than necrosis, hepatocellular hypertrophy from male rats in the subchronic study (Loveless et al., 2009) was selected over the candidate value for necrosis.

The candidate toxicity value of 5 × 10^−3^ mg/kg-d PFHxA for decreased RBCs in female rats from the chronic study was selected as the hematopoietic osRfD. Although the candidate value for the subchronic study (3 × 10^−4^ mg/kg-d PFHxA) was lower than that for the chronic study, confidence in the POD from the subchronic study was reduced as the unadjusted POD was well below the observed NOAEL in the study and may have been driven largely by variability in the data. Note that the unadjusted PODs for decreased RBCs in the other subchronic study datasets were more similar to the POD from the chronic study as shown in Table 5-7. Further, the subchronic study may poorly predict a chronic exposure setting across multiple RBC life cycles (one cycle is ~60 days), which could reflect cumulative effects as greater proportions of RBCs across stages are affected, or possibly even reduced effects (compensatory responses). Therefore, the value from the chronic study was interpreted as the most appropriate value for use in addressing the potential hematopoietic effects of lifetime exposure.

The candidate toxicity value of 5 × 10^−4^ mg/kg-d PFHxA for decreased F_1_ offspring body weight at PND 0 rats (Loveless et al., 2009) was selected as the developmental osRfD. This candidate value was selected over the candidate value for increased perinatal mortality in mice (Iwai and Hoberman, 2014) because changes in fetal body weight are less severe and candidate value was substantially lower than fetal mortality. Therefore, this value is interpreted as protective of all developmental effects, including the increases in perinatal mortality in mice. In addition, of the two study designs, Loveless et al. (2009) included a longer exposure that spanned the entirety of gestation (exposure continued through the end of lactation, but the effect in question was measured on PND 0) versus Iwai and Hoberman (2014) where mouse offspring were exposed from GD 6–18; thus, the study in rats may encompass a greater proportion of the relevant critical windows for the developmental effects of PFHxA exposure.

Table 5-8 Confidence in the organ/system specific RfDs for PFHxA

Confidence categories | Designation | Discussion
Hepatic osRfD = 4 × 10^−4^ mg/kg-d PFHxA; 4 × 10^−4^ mg/kg-d PFHxA-Na and PFHxA-NH_4_
Confidence in the study used to derive osRfD | High | Confidence in the study (Loveless et al., 2009) is high based on the study evaluation results (i.e., rated high confidence overall) (HAWC link (https://hawcprd.epa.gov/rob/study/100517562/)). The overall study size, design, and test species were considered relevant for deriving toxicity values.
Confidence in the evidence base for hepatic effects | Medium | Confidence in the oral toxicity evidence base for hepatic effects is medium based on consistent, dose-dependent, and biologically coherent effects on organ weight and histopathology observed in multiple high confidence subchronic and chronic studies. The available mechanistic evidence also supports biological plausibility of the observed effects. Limitations of the evidence base for hepatic effects is the lack of human studies, and measures that would have been useful to inform the pathways for hepatic effects leading to hepatocellular hypertrophy (e.g., specific histological stains for hepatic vacuole contents).
Confidence in quantification of the POD_HED_ | Medium | Confidence in the quantification of the POD and osRfD is medium, given the POD was based on BMD modeling within the range of the observed data and dosimetric adjustment based on PFHxA-specific PK information. Some residual uncertainty in the application of the dosimetric approach described above is that V_d_ and CL were not measured in humans or mice and were considered equivalent to those for monkeys and rats, respectively.
Overall confidence in the hepatic osRfD | Medium | The overall confidence in the osRfD is medium and is primarily driven by medium confidence in the overall evidence base for hepatic effects, high confidence in the study, and medium confidence in quantitation of the POD. High confidence in the study was not interpreted to warrant changing the overall confidence from medium.
Hematopoietic osRfD = 5 × 10^−3^ mg/kg-d PFHxA and PFHxA-NH_4_; 6 × 10^−3^ mg/kg-d PFHxA-Na
Confidence in study | High | Confidence in the study (Klaunig et al., 2015) is high based on the study evaluation results (i.e., rated high confidence overall) (HAWC link (https://hawcprd.epa.gov/rob/study/100517532/)) and characteristics that make it suitable for deriving toxicity values, including relevance of the exposure paradigm (route, duration, and exposure levels), use of a relevant species, and the study size and design.
Confidence in evidence base for hematopoietic effects | Medium | Confidence in the evidence base for hematopoietic effects was medium based on consistent and biologically coherent effects on red blood cells, hemoglobin, and other hematological parameters measured across multiple high confidence chronic and subchronic studies. The RBC and hemoglobin findings were correlative with an erythrogenic response indicated by increased reticulocytes and pathological findings of splenic extramedullary hematopoiesis and bone marrow erythroid hyperplasia. Limitations of the hematopoietic evidence base are lack of human studies, and some hematological measures were observed only at the highest dose, limiting interpretation of dose-response.
Confidence in the quantification of the POD_HED_ | Medium | Confidence in the quantification of the POD and osRfD is medium given the POD was based on BMD modeling within the range of the observed data and dosimetric adjustment based on PFHxA-specific PK information. Some residual uncertainty in the application of the dosimetric approach described above is that V_d_ and CL were not measured in humans or mice and were considered equivalent to those for monkeys and rats, respectively. Some additional residual uncertainty in POD quantitation was due to the availability of a much lower POD, and the dose spacing was biased toward low end of the dose range.
Confidence in hematopoietic osRfD | Medium | The overall confidence in the osRfD is medium and is primarily driven by medium confidence in the overall evidence base for hematopoietic effects, and medium confidence in quantitation of the POD. High confidence in the study was not interpreted to warrant changing the overall confidence from medium.
Developmental osRfD = 5 × 10^−4^ mg/kg-d PFHxA; 5 × 10^−4^ mg/kg-d PFHxA-Na and PFHxA-NH_4_
Confidence in study | High | Confidence in the study (Loveless et al., 2009) is high based on study evaluation results (i.e., rated high confidence overall) (HAWC link (https://hawcprd.epa.gov/rob/study/100517562/)) and characteristics that make it suitable for deriving toxicity values, including relevance of the exposure paradigm (route, duration, and exposure levels), use of a relevant species, and the study size and design.
Confidence in evidence base for developmental effects | Medium | Confidence in evidence base for developmental effects is medium based on the availability of data from two studies in different species (i.e., rats and mice) that consistently observed decreases in offspring body weight and coherent increases in perinatal mortality. Areas of uncertainty included lack of human data and multigenerational animal toxicity studies. Also, data to inform other organ/system-specific hazards (e.g., thyroid, immune, nervous system) following a developmental exposure are lacking. Together these present significant data gaps in the potential effects during this sensitive life stage.
Confidence in the quantification of the POD_HED_ | Medium | Confidence in the quantification of the POD and osRfD is medium given the POD was based on BMD modeling within the range of the observed data and dosimetric adjustment based on PFHxA-specific PK information. Some residual uncertainty in the application of the dosimetric approach described above is that V_d_ and CL were not measured in humans or mice and were considered equivalent to those in monkeys and rats, respectively.
Confidence in developmental osRfD | Medium | The overall confidence in the osRfD is medium and is primarily driven by medium confidence in the overall evidence base for developmental effects, high confidence in the study, and medium confidence in quantitation of the POD. High confidence in the study was not interpreted to warrant changing the overall confidence from medium.

##### Selection of the overall oral reference dose and confidence statements

Table 5-9 Organ/system specific RfD values for PFHxA

System | Basis | POD_HED_ | UF_C_ | osRfD for PFHxA (mg/kg-d) | osRfD for PFHxA-Na^a^ (mg/kg-d) | osRfD for PFHxA-NH4^a^ (mg/kg-d) | Confidence
Hepatic | Increased hepatocellular hypertrophy in adult male Crl:CD Sprague-Dawley rats | 0.11 mg/kg-d based on BMDL_10ER_ and free salt normalization; (Loveless et al., 2009) | 300 | 4 × 10^−4^ | 4 × 10^−4^ | 4 × 10^−4^ | Medium
Hematopoietic | Decreased red blood cells in adult female Crl:CD Sprague-Dawley rats | 0.52 mg/kg-d based on BMDL_1SD_; (Klaunig et al., 2015) | 100 | 5 × 10^−3^ | 6 × 10^−3^ | 5 × 10^−3^ | Medium
Developmental (selected as RfD) | Decreased postnatal (PND 0) body weight in F_1_ Sprague-Dawle y male and female rats, exposed throughout gestation and lactation | 0.048 mg/kg-d based on BMDL_5RD_ and free salt normalization; (Loveless et al., 2009) | 100 | 5 × 10^−4^ | 5 × 10^−4^ | 5 × 10^−4^ | Medium

a To calculate candidate values for salts of PFHxA, multiply the candidate value of interest by the ratio of molecular weights of the free acid and the salt. For example, for the sodium salt of PFHxA, the candidate value would be calculated by multiplying the free acid candidate value by 1.070 (MW free acid/MW sodium salt = 336/314 = 1.070). This same conversion can be applied to other salts of PFHxA, such as the ammonium salt.

From the identified human health effects of PFHxA and derived osRfDs for hepatic, hematopoietic, and developmental effects (see Table 5-9), an RfD of 5 × 10^−4^ mg/kg-day PFHxA based on decreased postnatal (F_1_) body weight in rats was selected. As described in Table 5-8, confidence in the RfD is medium, based on medium confidence in the developmental RfD. The decision to select the developmental RfD was based on all available osRfDs in addition to overall confidence and composite uncertainty for those osRfDs. The confidence in the selected RfD is equivalent to that of the hepatic and hematopoietic RfDs. The developmental endpoint decreased F_1_ body weight at PND 0 having the lowest overall POD_HED_ of 0.048 mg/kg-d PFHxA based on BMDL_5RD_ and free salt normalization (Loveless et al., 2009) and UF_C_ of 100 was considered protective across all lifestages. The hepatic RfD was slightly lower but was based on a higher POD_HED_ (0.11 mg/kg-day PFHxA) and UF_C_ (300). The developmental RfD, therefore, is based on the lowest POD_HED_ and lowest UF_C_ using a study considered high confidence.

#### Estimation or Selection of Points of Departure (PODs) for Subchronic RfD Derivation

In addition to providing an RfD for lifetime exposure in health systems, this document also provides an RfD for less-than-lifetime (“subchronic”) exposures. These subchronic RfDs were based on the endpoints advanced for POD derivation provided in Table 5-1. Data to inform potential hepatic and hematopoietic effects from the high confidence subchronic studies by (Chengelis et al., 2009b; Loveless et al., 2009) were considered the most informative for developing candidate values. The high confidence developmental/reproductive studies (Iwai and Hoberman, 2014; Loveless et al., 2009) were also advanced for candidate value derivation. While it was not advanced for a lifetime RfD, the high confidence short-term study (NTP, 2018) was considered for subchronic candidate value derivation for endocrine effects. In general, the rationales for advancing these endpoints for subchronic value derivation are the same as described and summarized above in Table 5-1; however, for hematopoietic effects, subchronic data from Chengelis et al. (2009b) and Loveless et al. (2009) were prioritized over the data from the chronic study by Klaunig et al. (2015) for use in deriving a subchronic RfD.

The endpoints selected for dose-response were modeled using approaches consistent with EPA’s Benchmark Dose Technical Guidance document (U.S. EPA, 2012a). The approach was the same as described above for derivation of lifetime toxicity values, the BMRs selected for dose-response modeling and the rationales for their selection (see Table 5-2), and the dosimetric adjustments using the ratio of the clearance in animal to that in the human and salt to free acid normalization. Table 5-10 presents the estimated POD_HED_ (mg/kg-day) values for the hepatic, developmental, and hematopoietic toxicity endpoints considered for subchronic RfD derivation.

Table 5-10 PODs considered for the derivation of the subchronic RfD

Endpoint | Study/confidence | Species, strain (sex) | POD type/model | POD (mg/kg-d) | POD_HED_ PFHxA^a^ (mg/kg-d)
Hepatic effects
↑Hepatocellular hypertrophy
↑Hepatocellular hypertrophy | Loveless et al. (2009); High confidence | Rat, Crl:CD(SD) (male) | BMDL_10ER_; Multistage 1 NCV | 10.66 | 0.11^c^
↑Hepatocellular hypertrophy | Loveless et al. (2009); High confidence | Rat, Crl:CD(SD) (female) | NOAEL^b^; (0% response) | 100 | 0.45^c^
Hematopoietic effects
↓Hemoglobin | Chengelis et al. (2009b); High confidence | Rat, Crl:CD(SD) (male) | BMDL_1SD_; Polynomial 3 CV | 81.35 | 0.89
↓Hemoglobin | Chengelis et al. (2009b); High confidence | Rat, Crl:CD(SD) (female) | NOAEL^d^; (3% decrease) | 50 | 0.24
↓Hemoglobin | Loveless et al. (2009); High confidence | Rat, Crl:CD(SD) (male) | NOAEL^d^; (6% decrease) | 202 | 0.21^c^
↓Hemoglobin | Loveless et al. (2009); High confidence | Rat, Crl:CD(SD) (female) | BMDL_1SD_; Polynomial 3 CV | 127.61 | 0.57^c^
↓Red blood cell | Chengelis et al. (2009b); High confidence | Rat, Crl:CD(SD) (male) | NOAEL^d^; (no change) | 50 | 0.55
↓Red blood cell | Chengelis et al. (2009b); High confidence | Rat, Crl:CD(SD) (female) | BMDL_1SD_; Exponential 5 CV | 16.32 | 0.078
↓Red blood cell | Loveless et al. (2009); High confidence | Rat, Crl:CD(SD) (male) | BMDL_1SD_; Linear NCV | 44.57 | 0.46^c^
↓Red blood cell | Loveless et al. (2009); High confidence | Rat, Crl:CD(SD) (female) | BMDL_1SD_; Linear CV | 112.36 | 0.50^c^
Developmental Effects
↓Postnatal (F_1_) body weight, PND 0 | Loveless et al. (2009); High confidence | Rat, Crl:CD(SD), F_1_ (combined) | BMDL_5RD_; Hill | 10.62 | 0.048^c^
↓Postnatal (F_1_) body weight, PND 0 | Iwai and Hoberman (2014); High confidence | Mouse, CD-1, F_1_ (combined) | BMDL_5RD_; Polynomial 3 CV; Phase 2 | 80.06 | 0.68^e^
↓Postnatal (F_1_) body weight, PND 4 | Iwai and Hoberman (2014); High confidence | Mouse, CD-1, F_1_ (combined) | BMDL_5RD_; Exponential-M5; Phase 1 and 2; Polynomial 3 CV; Phase 2 | 102.94; 89.79 | 0.87^e^; 0.76^e^
↑Perinatal Mortality | Iwai and Hoberman (2014); High confidence | Mouse, CD-1, F_1_ (combined) | BMDL_1ER_; Nested Logistic; Phase 2 | 24.77 | 0.21^e^
Endocrine effects
↓ Total T4 | NTP (2018); High confidence | Rat, Harlan Sprague-Dawley (male) | BMDL_1SD_; Hill CV | 25.97 | 0.29

1SD = 1 standard deviation, CV = constant variance, NCV = nonconstant variance.

a HED calculations based on the DAF, the ratio of human and animal clearance values (see Table 5-3). DAF values for female rats and female mice were used for the respective developmental effects on combined male and female pups of each species. POD_HED_ based on PFHxA free acid.

b Response only at high dose with responses far above BMR level, data not modeled.

c POD_HED_ multiplied by normalization factor to convert from sodium salt to free acid (MW free acid/MW sodium salt = 314/336 = 0.935).

d No models provided adequate fit; therefore, a NOAEL approach was selected.

e POD_HED_ multiplied by normalization factor to convert from sodium salt to free acid (MW free acid/MW ammonium salt = 314/331 = 0.949).

#### Derivation of Candidate Toxicity Values for the Subchronic RfD

The POD_HED_ values listed in Table 5-10 were further narrowed for selecting candidate toxicity values for subchronic osRfD derivation and subchronic RfD selection. As described for the RfD, RBCs were a more sensitive POD_HED_ for hematopoietic effects. Therefore, the red blood cell endpoint from female rats from Chengelis et al. (2009b) was advanced as the candidate toxicity value for subchronic RfD derivation over male endpoints for hematocrit and red blood cells based on RBC being more sensitive and therefore expected to be protective of effects in both sexes. Applying the rationales described for the selection of the lifetime osRfDs, the same endpoints were advanced as the candidate toxicity values for derivation of the hepatic and developmental subchronic osRfDs: male hepatocellular hypertrophy and decreased F_1_ body weight at PND 0 (Loveless et al., 2009). For endocrine effects, a candidate toxicity value for the subchronic RfD was derived based on a short-term study showing decreased total T4 in adult male rats exposed for 28 days. Due to the high uncertainty associated with deriving a lifetime value based on a short-term study this endpoint was not considered for the RfD but was advanced for the subchronic RfD.

As described above under “Derivation of Candidate Values for the RfD,” and in U.S. EPA (2002c), five possible areas of uncertainty and variability were considered in deriving the candidate subchronic toxicity values for PFHxA. In general, the explanations for these five possible areas of uncertainty and variability and the values assigned to each as a designated UF to be applied to the candidate POD_HED_ values are listed above and in Table 5-6, including the UF_D_ which remained at 3 due to data gaps (i.e., for most outcomes, a lack of: informative human studies, animal studies from multiple species or spanning multiple generations, studies of other organ/system-specific effects associated with other PFAS, including PFOA and PFOS, particularly following developmental exposure). The exception that a UF_S_ = 1 was applied for all endpoints since no subchronic to chronic extrapolation was required for the candidate toxicity values for the subchronic RfD. For the endocrine endpoint, a UFs = 3 was applied. Although the data are derived from a short-term (28-day) study, the life cycle of T4 occurs on the order days or less [t_½_ is approximately 12 hours (Döhler et al., 1979)], therefore, the short-term study duration is expected to capture effects for all components of the T4 life cycle and uncertainty about the ability of PFHxA exposure to affect following a 28-day exposure is reduced. Considering this along with the short half-life (hours) of PFHxA in rats (see Section 3.1) and the approximate 3-fold difference in duration between this study and a guideline subchronic study (i.e., 90 days), a UF_S_ = 3 was deemed most appropriate. The resulting candidate toxicity values are shown in Table 5-11.

Table 5-11 Candidate subchronic toxicity values for PFHxA

Endpoint/study/confidence | Species, strain (sex) | POD_HED_ PFHxA^a^ (mg/kg-d) | UF_A_ | UF_H_ | UF_S_ | UF_L_ | UF_D_ | UF_C_ | Candidate value PFHxA (mg/kg-d) | Candidate value PFHxA-Na^c^ (mg/kg-d) | Candidate value PFHxA-Na^c^ (mg/kg-d)
Hepatic effects
↑Hepatocellular hypertrophy, 90 d; Loveless et al. (2009); High confidence | Rat, Crl:CD(SD) (male) | 0.11^b^ | 3 | 10 | 1 | 1 | 3 | 100 | 1 × 10^−3^ | 1 × 10^−3^ | 1 × 10^−3^
Hematopoietic effects
↓Red blood cell, 90 d; Chengelis et al. (2009b); High confidence | Rat, Crl:CD(SD) (female) | 0.078 | 3 | 10 | 1 | 1 | 3 | 100 | 8 × 10^−4^ | 8 × 10^−4^ | 8 × 10^−4^
Developmental effects
↓Postnatal (F_1_) body weight, PND 0; Loveless et al. (2009); High confidence | Rat, Sprague-Dawley, F1 (combined) | 0.048^b^ | 3 | 10 | 1 | 1 | 3 | 100 | 5 × 10^−4^ | 5 × 10^−4^ | 5 × 10^−4^
↑Perinatal Mortality, PND 0-21; Iwai and Hoberman (2014); High confidence | Mouse, CD-1, F1 (combined) | 0.21 | 3 | 10 | 1 | 1 | 3 | 100 | 2 × 10^−3^ | 2 × 10^−3^ | 2 × 10^−3^
Endocrine effects
↓ Total T4; NTP (2018); High confidence | Rat, Harlan Sprague-Dawley (male) | 0.29 | 3 | 10 | 3 | 1 | 3 | 300 | 1 × 10^−3^ | 1 × 10^−3^ | 1 × 10^−3^

a The RfD for the free acid of PFHxA is calculated using the ratio of molecular weights as described above.

b POD_HED_ multiplied by normalization from the sodium salt to free acid (MW free acid/MW sodium salt = 314/336 = 0.935).

c To calculate subchronic candidate values, osRfDs or the subchronic RfD for salts of PFHxA, multiply the value of interest by the ratio of molecular weights of the salt and free acid. For example, for the sodium salt of PFHxA, the candidate value is calculated by multiplying the free acid candidate value by 1.070: (MW free acid/MW sodium salt = 336/317 = 1.070).

##### Selection of Subchronic Organ- or System-Specific RfDs

As described above, subchronic osRfDs associated with each health effect are presented as they may be useful for certain decision purposes (i.e., site-specific risk assessments with less-than-lifetime exposures). Confidence in each subchronic osRfD are described in Table 5-12 and consider confidence in the study used to derive the quantitative estimate, the overall health effect, specific evidence base, and quantitative estimate for each subchronic osRfD.

Table 5-12 Confidence in the subchronic organ/system specific RfDs for PFHxA

Confidence categories | Designation | Discussion
Hepatic subchronic osRfD = 1 × 10^−3^ mg/kg-d PFHxA; 1 × 10^−3^ mg/kg-d PFHxA-Na or PFHxA-NH_4_
Confidence in the study used to derive the subchronic osRfD | High | Confidence in the study (Loveless et al., 2009) is high based on the study evaluation results (i.e., rated high confidence overall) HAWC link (https://hawcprd.epa.gov/rob/study/100517562/)) and characteristics that make it suitable for deriving toxicity values, including relevance of the exposure paradigm (route, duration, and exposure levels), use of a relevant species, and the study size and design.
Confidence in the evidence base for hepatic effects | Medium | Confidence in the oral toxicity evidence base for hepatic effects is medium based on consistent, dose-dependent, and biologically coherent effects on organ weight and histopathology observed in multiple high confidence subchronic and chronic studies. The available mechanistic evidence also supports biological plausibility of the observed effects. Limitations of the evidence base for hepatic effects is the lack of human studies, and measures that would have been useful to inform the pathways for hepatic effects leading to hepatocellular hypertrophy (e.g., specific stains for hepatic vacuole contents, specific histological for pathology).
Confidence in quantification of the POD_HED_ | Medium | Confidence in the quantification of the POD and subchronic osRfD is medium given the POD was based on BMD modeling within the range of the observed data and dosimetric adjustment based on PFHxA-specific PK information. Some residual uncertainty in the application of the dosimetric approach described above is that V_d_ and CL were not measured in humans or mice and were considered equivalent to those in monkeys and rats, respectively.
Overall confidence in the hepatic subchronic osRfD | Medium | The overall confidence in the subchronic osRfD is medium and is primarily driven by medium confidence in the overall evidence base for hepatic effects, high confidence in the study, and medium confidence in quantitation of the POD. High confidence in the study was not interpreted to warrant changing the overall confidence from medium.
Hematopoietic subchronic osRfD = 8 × 10^−4^mg/kg-d PFHxA; 8 × 10^−4^mg/kg-d PFHxA-Na or PFHxA-NH_4_
Confidence in study used to derive the subchronic osRfD | High | Confidence in the study (Chengelis et al., 2009b) is high based on the study evaluation results (i.e., rated high confidence overall) (HAWC link (https://hawcprd.epa.gov/rob/study/100517534/)) and characteristics that make it suitable for deriving toxicity values, including relevance of the exposure paradigm (route, duration, and exposure levels), use of a relevant species, and the study size and design.
Confidence in evidence base for hematopoietic effects | High | Confidence in the evidence base for hematopoietic effects was high based on consistent and biologically coherent effects on red blood cells, hemoglobin, and other hematological parameters measured across multiple high confidence chronic and subchronic studies. The RBC and hemoglobin findings were also coherent with an erythrogenic response indicated by increased reticulocytes and pathological findings of splenic extramedullary hematopoiesis and bone marrow erythroid hyperplasia. Limitations of the hematopoietic evidence base are lack of human studies, and some hematological measures were observed only at the highest dose, limiting interpretation of dose-response.
Confidence in quantification of the POD_HED_ | Low | Confidence in the quantification of the POD and subchronic osRfD is low given the POD was far below the NOAEL (50 mg/kg-d) and the osRfD is far below toxicity values derived for the same finding from other subchronic studies suggesting some underlying variability driving the POD lower.
Confidence in hematopoietic subchronic osRfD | Medium-Low | The overall confidence in the subchronic osRfD is medium-low and is primarily driven by low quantitation of the POD. High confidence in the study was not interpreted to warrant changing the overall confidence from medium-low.
Developmental subchronic osRfD = 5 × 10^−4^ mg/kg-d PFHxA; 5 × 10^−4^ mg/kg-d PFHxA-Na or PFHxA-NH_4_
Confidence in study used to derive the subchronic osRfD | High | Confidence in the study (Loveless et al., 2009) is high based on the study evaluation results (i.e., rated high confidence overall) (HAWC link (https://hawcprd.epa.gov/rob/study/100517562/)) and characteristics that make it suitable for deriving toxicity values, including relevance of the exposure paradigm (route, duration, and exposure levels), use of a relevant species, and the study size and design.
Confidence in evidence base for developmental effects | Medium | Confidence in evidence base for developmental effects is medium based on the availability of data from two studies in different species (i.e., rats and mice) that consistently observed decreases in offspring body weight and coherent increases in mortality. One area of uncertainty is that there were no multigenerational studies available. Also, data to inform other organ/system-specific hazards (e.g., thyroid, immune, nervous system) following a developmental exposure is lacking. Together these present significant data gaps in the potential effects during this sensitive life stage.
Confidence in the quantification of the POD_HED_ | Medium | Confidence in the quantification of the POD and subchronic osRfD is medium given the POD was based on BMD modeling, within the range of the observed data and dosimetric adjustment based on PFHxA-specific PK information. Some residual uncertainty in the application of the dosimetric approach described above is that V_d_ and CL were not measured in humans or mice and were considered equivalent to those in monkeys and rats, respectively.
Confidence in developmental subchronic osRfD | Medium | The overall confidence in the subchronic osRfD is medium and is primarily driven by medium confidence in the overall evidence base for developmental effects, high confidence in the study, and medium confidence in quantitation of the POD. High confidence in the study was not interpreted to warrant changing the overall confidence from medium.
Endocrine subchronic osRfD = 1 × 10^−3^ mg/kg-d PFHxA; 1 × 10^−3^ mg/kg-d PFHxA-Na or PFHxA-NH_4_
Confidence in study used to derive the subchronic osRfD | High | Confidence in the study (NTP, 2018) is high based on the study evaluation results (i.e., rated high confidence overall) (HAWC link (https://hawcprd.epa.gov/rob/study/100517547/)) and characteristics that make it suitable for deriving toxicity values, including relevance of the exposure paradigm (route and exposure levels), use of a relevant species, and the study size and design.
Confidence in evidence base for endocrine effects | Medium-Low | Confidence in the oral toxicity evidence base for endocrine effects is medium-low based primarily on strong dose-dependent effects on serum T4 in males reported in a high confidence short-term study. This finding is consistent with effects observed in a low confidence human study and a zebrafish study. The available mechanistic evidence supports biological plausibility of the observed effects in rodents. Limitations of the evidence base for endocrine effects is the lack of informative human studies and longer duration studies in animals. Additionally, studies to inform the pathways for thyroid effects leading changes in thyroid hormone levels and/or sex specific differences.
Confidence in the quantification of the POD_HED_ | Medium | Confidence in the quantification of the POD and subchronic osRfD is medium given the POD was based on BMD modeling within the range of the observed data and dosimetric adjustment based on PFHxA-specific PK information. Some residual uncertainty in the application of the dosimetric approach described above is that V_d_ and CL were not measured in humans or mice and were considered equivalent to those in monkeys and rats, respectively.
Confidence in endocrine subchronic osRfD | Medium | The overall confidence in the subchronic osRfD is medium and is primarily driven by medium-low confidence in the overall evidence base for developmental effects, high confidence in the study, and medium confidence in quantitation of the POD. High confidence in the study was not interpreted to warrant changing the overall confidence from medium.

##### Selection of Subchronic RfD and Confidence Statement

Organ/system-specific subchronic RfD values for PFHxA are summarized in Table 5-13.

Table 5-13 Subchronic osRfD values for PFHxA

System | Basis | POD_HED_ | UF_C_ | osRfD for PFHxA (mg/kg-d) | osRfD for PFHxA-Na^a^ (mg/kg-d) | osRfD for PFHxA-NH_4_^a^ (mg/kg-d) | Confidence
Hepatic | Increased hepatocellular hypertrophy in adult male Crl:CD Sprague-Dawley rats | 0.11 mg/kg-d based on BMDL_10ER_ and free salt normalization; (Loveless et al., 2009) | 100 | 1 × 10^−3^ | 1 × 10^−3^ | 1 × 10^−3^ | Medium
Hematopoietic | Decreased red blood cells in adult female Crl:CD Sprague-Dawley rats | 0.078 mg/kg-d based on BMDL_1SD_; (Chengelis et al., 2009b) | 100 | 8 × 10^−4^ | 8 × 10^−4^ | 8 × 10^−4^ | Medium-Low
Developmental | Decreased postnatal (PND 0) body weight in F1 Sprague-Dawley male and female rats, exposed throughout lactation and gestation | 0.048 mg/kg-d based on BMDL_5RD_ and free salt normalization; (Loveless et al., 2009) | 100 | 5 × 10^−4^ | 5 × 10^−4^ | 5 × 10^−4^ | Medium
Endocrine | Decreased total T4 in adult male Harlan Sprague-Dawley rats | 0.29 mg/kg-d based on BMDL_1SD_ (NTP, 2018) | 300 | 1 × 10^−3^ | 1 × 10^−3^ | 1 × 10^−3^ | Medium

a To calculate candidate values for salts of PFHxA, multiply the candidate value of interest by the ratio of molecular weights of the free acid and the salt. For example, for the sodium salt of PFHxA, the candidate value would be calculated by multiplying the free acid candidate value by 1.070 (MW free acid/MW sodium salt = 336/314 = 1.070). This same conversion can be applied to other salts of PFHxA, such as the ammonium salt.

From the identified targets of PFHxA toxicity and derived subchronic osRfDs (see Table 5-13), a subchronic RfD of 5 × 10^−4^ mg/kg-day based on decreased postnatal body weight is selected for less-than-lifetime exposure. Confidence in the subchronic RfD is medium, based on medium confidence in the developmental subchronic RfD, as described in Table 5-12. The confidence in the selected subchronic RfD is equivalent to that of the hepatic subchronic RfDs and higher than the hematopoietic subchronic RfD. The developmental subchronic RfD is expected to be protective of all life stages. The UF_C_ (see Table 5-13) is lower than or equivalent to the other subchronic osRfDs and the endpoint has the lowest POD_HED_ (0.048 mg/kg-day, see Table 5-11). The decision to select the developmental subchronic RfD was based on all the available subchronic osRfDs in addition to overall confidence and composite uncertainty for those subchronic osRfDs.

### 5.2.2 Inhalation Reference Concentration (RfC)

No published studies investigating the inhalation effects of subchronic, chronic, or gestational exposure to PFHxA in humans or animals have been identified. Therefore, an RfC is not derived.

## 5.3 CANCER TOXICITY VALUES

As discussed in Sections 3.3 and 4.2, given the sparse evidence base and in accordance with the Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005), EPA concluded that there is inadequate information to assess carcinogenic potential for PFHxA for any route of exposure. Therefore, consistent with the Guidelines and the lack of adequate data on the potential carcinogenicity of PFHxA, quantitative estimates for either oral (oral slope factor, OSF) or inhalation (inhalation unit risk; IUR) exposure were not derived.