# 4 SUMMARY OF HAZARD IDENTIFICATION CONCLUSIONS

## 4.1 SUMMARY OF CONCLUSIONS FOR NONCANCER HEALTH EFFECTS

For all noncancer health effects, limited or no human epidemiological evidence was available. Therefore, conclusions were based primarily on animal toxicological studies. The animal evidence base consists of a short-term daily exposure to 0, 62.5, 125, 250, 500, 1000 mg/kg PFHxA for 28 days (NTP, 2018), subchronic daily exposure to 0, 10, 50, 200 mg/kg PFHxA (Chengelis et al., 2009b), subchronic daily exposure to 0, 20, 100, 500 mg/kg PFHxA sodium salt (Loveless et al., 2009), and chronic daily exposure for two years to 0, 5, 30, 200 mg/kg or 0, 2.5, 15, 100 mg/kg PFHxA female or male respectively (Klaunig et al., 2015). Two developmental, gestational exposure, studies (Iwai and Hoberman, 2014; Loveless et al., 2009) and a one-generation reproductive study (Loveless et al., 2009) with maternal oral doses between 7–500 mg/kg-day also were also available. The outcome-specific ratings for these studies were generally high confidence.

As described in detail in Section 3, the available evidence indicates that PFHxA exposure is likely to cause hepatic (Section 3.2.1), developmental (Section 3.2.2), hematopoietic (Section 3.2.4), and endocrine effects (Section 3.2.5) in humans, given sufficient exposure conditions. As previously noted, the “sufficient exposure conditions” are more fully evaluated and defined for the identified health effects through dose-response analysis in Section 5.

The evidence for PFHxA-mediated adverse hepatic effects was based primarily on a set of consistent and coherent findings in animal studies, including hepatocellular hypertrophy and increased relative liver weight, generally at ≥100 mg/kg-day PFHxA. Most of the hepatic effects observed in rodents changed in a consistent direction between sexes and across studies, however the magnitude of change was often greater in males compared with females possibly due to faster PFHxA clearance in females compared with males (see Section 3.1.4). Hepatic hypertrophy persisted after recovery in the subchronic studies and was coherent with findings of increased peroxisomal beta oxidation in animals. Hepatic hypertrophy was not observed after chronic exposure, possibly because of the tested dose levels (e.g., male rats in the chronic study were maximally exposed to PFHxA doses 2- to 5-fold below the maximal doses in the two subchronic studies) or other study design differences. Interestingly, necrosis was observed in the female high dose group (200 mg/kg-day) in the chronic study, suggesting that with longer term exposure, hepatocellular hypertrophy could progress to more severe outcomes such as necrosis. These effects in rodents were evaluated together along with supplemental evidence, including mechanistic and pharmacokinetics information, to consider whether the rodent effects represent adverse or adaptive changes to PFHxA exposure and their human relevance. Regarding human relevance, the hepatocellular hypertrophy findings were coherent with mechanistic findings on the activation of target genes and transcription factors, including PPARα, in human and rat cell systems treated with PFHxA. While the role of PPARα was not specifically challenged in rodent models exposed to PFHxA, evidence that PFHxA activates both human and rodent PPARα at comparable concentrations, alongside evidence from structurally similar PFAS, indicates that PPARα dependent and independent hepatic effects are both likely contributing to the hepatic effects of PFHxA and that these effects are relevant to humans. Regarding adversity, the histologic changes (increased hypertrophy and necrosis) were coherent with clinical pathology findings (including increased ALT and decreased serum globulins) and collectively considered in the context of the Hall criteria (see Section 3.2.1) as adverse.

The data from the animal toxicological studies that support identifying developmental effects as a potential human hazard included effects from three studies that reported consistent, dose-responsive, and concerning effects of PFHxA exposure on offspring body weights and mortality. Delayed eye opening was also reported. The observed developmental effects following PFHxA exposure are similar to other PFAS, including PFBS (U.S. EPA, 2021b) and PFBA (U.S. EPA, 2022b), providing additional support for these specific findings. Effects on offspring body weight were observed in two species (rats and mice) exposed to different PFHxA salts (sodium and ammonium) using different exposure scenarios, although effects on mortality were observed only in the mouse study. Low birth weight is associated with lasting adverse effects on health, with increased risk for disease and reductions in lifespan in humans (Thompson and Regnault, 2011; Kajantie et al., 2005; Barker, 2004) and delays in eye opening can impact normal development of the visual system (Espinosa and Stryker, 2012; Wiesel, 1982).

The primary support for hematopoietic effects included consistent decreases in red blood cells, hematocrit, and hemoglobin across study designs and exposure durations in male and female adult rats (NTP, 2018; Chengelis et al., 2009b; Loveless et al., 2009). These hematological findings correlate with increases in reticulocytes, an indicator of erythroid cell regeneration supported by pathological findings in the spleen and bone marrow (Loveless et al., 2009). The decreases in hemoglobin were consistent with the decreased mean corpuscular hemoglobin concentration observed in both sexes (NTP, 2018; Loveless et al., 2009). When combined, increased mean corpuscular hemoglobin concentration (MCHC), and mean corpuscular volume (MCV) are indicators of anemia. Several of the hematological findings were significant at the highest dose tested in the subchronic studies and returned to control levels after 30- or 90-day recovery periods (or both) (Chengelis et al., 2009b; Loveless et al., 2009). Findings from females in the chronic study (e.g., HGB, RBC, and reticulocytes) were significant at the highest administered dose (200 mg/kg-day), whereas no effects were observed in males that received half (100 mg/kg-day) the female dose. Together, the subchronic and chronic evidence from males and female rats suggest PFHxA-mediated hematopoietic effects are dependent on both dose and duration.

For endocrine effects, the evidence to support PFHxA mediated effects is largely based on a short-term study in rats showing a strong dose-dependent effect on thyroid hormones (decreased serum T4 and T3, with no significant changes in TSH) in males only (NTP, 2018). This pattern of thyroid hormone changes in rats is consistent with findings for other short-chain PFAS with more substantial evidence bases, namely PFBA and PFBS, increasing the certainty in this evidence. These rodent PFHxA data are also supported by similar findings in early lifestage zebrafish (Zhang et al., 2022). Effects on thyroid histopathology and thyroid weight were also investigated in several rat studies ranging from short-term to chronic exposure durations (NTP, 2018; Klaunig et al., 2015; Chengelis et al., 2009b; Loveless et al., 2009). Of these, only Loveless et al. (2009) found treatment related increases in thyroid follicular cell hypertrophy and organ weight. Additionally, some mechanistic evidence is available that suggests PFHxA may affect thyroid function by altering expression of thyroid-associated mRNA and proteins or binding with serum transport proteins or the nuclear receptor.

There evidence is inadequate to determine whether PFHxA has the potential to cause renal, male, and female reproductive, immune, and nervous system effects in humans. renal, male, and female reproductive, immune, and nervous system. There was insufficient evidence to determine whether PFHxA exposure has the potential to cause other health effects (e.g., ocular effects, cardiovascular, respiratory, gastrointestinal). Other potential health outcomes have not been evaluated in the context of PFHxA exposure. Thus, important data gaps for PFHxA exists given the associations observed for other PFAS, such as PFBS, PFOA, PFOS, and GenX (U.S. EPA, 2021a; MDH, 2020, 2019, 2018; U.S. EPA, 2018b, 2016a, b). See Table 4-1 for a comparison of the noncancer hazard judgments drawn for PFHxA with the judgments in the final EPA assessments for PFBS, PFOA, PFOS, and GenX.

Table 4-1 Hazard conclusions across published EPA PFAS human health assessments

Health outcome | PFAS assessments^a,b,c^
Health outcome | PFHxA; (this assessment) | PFBA; U.S. EPA (2022b) | PFBS^d^; U.S. EPA (2018b) | Gen X chemicals^d^; U.S. EPA (2021a) | PFOA^d^; U.S. EPA (2023b) | PFOS^d^; U.S. EPA (2023a)
Endocrine/Thyroid | + | + | + | ND | Human: + | Human: +/−; Animal: +/−
Endocrine/Thyroid | + | + | + | ND | Animal: +/− | Human: +/−; Animal: +/−
Hepatic/Liver | + | + | − | + | Human: +; Animal: + | Human: −
Hepatic/Liver | + | + | − | + | Human: +; Animal: + | Animal: +
Developmental | + | + | + | +/− | Human: +; Animal: + | Human: +; Animal: +
Reproductive | − | − | − | +/− | Human: − | ND
Reproductive | − | − | − | +/− | Animal: +/− | ND
Immunotoxicity | − | − | − | +/− | Human: +; Animal: + | Human: +/−
Immunotoxicity | − | − | − | +/− | Human: +; Animal: + | Animal: +
Renal | − | − | + | +/− | Human: +/−; Animal: +/− | ND
Hematopoietic/Hematological | + | − | ND | +/− | ND | ND
Ocular | ND | − | ND | ND | ND | ND
Serum Lipids | ND | ND | − | ND | Human: +; Animal: + | Human: +
Hyperglycemia | ND | ND | ND | ND | Human: −; Animal: − | Animal: +/−
Nervous System | − | ND | ND | ND | Human: −; Animal: − | Animal: +/−
Cardiovascular | ND | ND | − | ND | ND | ND
Cancer | − | − | − | +/− | +/− | +/−

a Assessments used multiple approaches for summarizing their noncancer hazard conclusion scales; for comparison purposes, the conclusions are presented as follows: ‘+’ = evidence demonstrates or evidence indicates (e.g., PFHxA), or evidence supports (e.g., PFBS); ‘+/−’ = suggestive evidence, ‘−’ = inadequate evidence (e.g., PFHxA) or equivocal evidence (e.g., PFBS); ‘−/−’ = sufficient evidence to conclude no hazard (no assessment drew this conclusion); ND = no data available for this outcome for this PFAS.

b The assessments all followed the EPA carcinogenicity guidelines (U.S. EPA, 2005) a similar presentation to that used to summarize the noncancer judgments is applied for the cancer hazard conclusions, as follows: ‘+’ = carcinogenic to humans or likely to carcinogenic to humans;’+/−’ = suggestive evidence of carcinogenic potential; ‘−’ = inadequate information to assess carcinogenic potential; ‘−/−’ = not likely to be carcinogenic to humans(no assessment drew this conclusion); ND = no carcinogenicity data available for this PFAS.

c The hazard conclusions for the various EPA PFAS assessments presented in this table were not considered during evidence integration and thus did not inform the evidence integration conclusions presented in the PFHxA assessment.

d The U.S. EPA PFOA (U.S. EPA, 2016b) and PFOS (U.S. EPA, 2016a) assessments did not use structured language to summarize the noncancer hazard conclusions. The presentation in this table was inferred from the hazard summaries found in the respective assessments; however, this is for comparison purposes only and should not be taken as representative of the conclusions from these assessments. Those interested in the specific noncancer hazard conclusions for PFOA and PFOS must consult the source assessments. Note that new assessments for PFOA and PFOS are currently being finalized to support a National Primary Drinking Water Regulation; note that hazard conclusions in these updated assessments will differ from those presented in this table as the new assessments use structured language to summarize the noncancer hazard conclusions. For access to the more recent draft assessment materials please follow this link (https://www.epa.gov/sdwa/and-polyfluoroalkyl-substances-pfas).

## 4.2 CONCLUSIONS REGARDING SUSCEPTIBLE POPULATIONS AND LIFESTAGES

No human studies were available to inform the potential for PFHxA exposure to affect sensitive subpopulations or lifestages.

In adult rats exposed to PFHxA for 28 days to 2 years, toxicological findings were either consistently observed at lower dose levels in males than females or the findings were observed only in males (except for necrosis in the chronic study). The reason for this sex dependence is possibly due to sex-dependent PFHxA elimination caused by sex-specific differences in the expression (mRNA and protein) of the renal organic anion transporting polypeptide (Oatp) 1a1 (Kudo et al., 2001) as discussed in Section 3.1.4. Currently, whether this sex-specific difference might also exist in humans is unclear.

Additionally, given the effects seen in the developing organism (i.e., perinatal mortality, reduced body weights, and delays in time to eye opening), the prenatal and early postnatal window represents a potentially sensitive lifestage for PFHxA exposure.

## 4.3 SUMMARY OF CONCLUSIONS FOR CARCINOGENICITY

The evidence is inadequate to make a judgment on whether PFHxA exposure might affect the development of any specific cancers (see Section 3.3). Given this general lack of evidence and consistent with EPA guidelines (U.S. EPA, 2005) instruction to apply a standard descriptor as part of the hazard narrative and to express a conclusion regarding the weight of evidence for the carcinogenic hazard potential, a descriptor of inadequate information to assess carcinogenic potential is applied for PFHxA; this descriptor is applicable across all exposure routes.