# 3 PHARMACOKINETICS, EVIDENCE SYNTHESIS, AND EVIDENCE INTEGRATION

## 3.1 PHARMACOKINETICS

Only a few human PK studies on PFHxA are available, but the studies provide sufficient data to estimate PFHxA half-life, a dependent variable for the estimation of clearance (along with volume of distribution). Several studies such as Ericson et al. (2007) reported PFHxA in blood or serum of human populations (e.g., in relation to age and sex) but, because exposure levels are not known for the subjects and the concentrations are not measured over time in specific subjects for whom the exposure level is known to be zero, such observations cannot be used to obtain ADME information. Several other studies that investigate specific aspects of PFHxA ADME in humans are discussed briefly below but were not used in the derivation of toxicity values. One analysis provides an estimate of PFHxA elimination in humans (Russell et al., 2013) using data from an observational study by Nilsson et al. (2013). Luz et al. (2019) describes a reanalysis of these data but based only on the three participants with the most rapid clearance. While EPA considers the data reported by Nilsson et al. (2013) to be sufficient for the estimation of a half-life in humans, the approaches used by Russell et al. (2013) and Luz et al. (2019) were not considered adequate. Therefore, the data of Nilsson et al. (2013) have been re-analyzed as described in Approach for Animal-Human Extrapolation of PFHxA Dosimetry (see Section 5.2.1).

Animal experiments in rats, mice, and monkeys have provided valuable information on PK processes of PFHxA. In brief, PFHxA and other perfluoroalkyl acids (PFAA) have similar PK aspects: They are well absorbed following oral exposure and quickly distribute throughout the body (Iwabuchi et al., 2017), particularly to blood, liver, skin, and kidney (Gannon et al., 2011). Dzierlenga et al. (2019) noted that following intravenous (i.v.) administration of 40 mg/kg PFHxA, the PK profiles were generally similar between sexes, but a lower dose-normalized area under the curve (AUC, 3.05 mM·h/mmol/kg), a faster clearance (CL, 327 mL/h-kg), and a lower volume of distribution of peripheral compartment (V_2_ = 59.6 mL/kg) was observed in female Sprague-Dawley rats, as compared to their male counterparts (dose-normalized AUC = 7.38 mM·h/(mmol/kg), CL = 136 mL/h-kg, and V_2_ = 271 mL/kg, respectively). Likewise, kinetic parameters (e.g., the maximum concentration [C_max_]) were comparable between sexes following an oral dose of 40 mg/kg, except that female rats exhibited a lower dose-adjusted AUC/dose and a faster CL. A PK study in mice similarly showed an AUC/dose in male animals 2–3 times higher than in females, indicating slower elimination in males (Gannon et al., 2011). Thus, apparent sex-related quantitative differences in PFHxA PK occur in rats and mice. On the other hand, the AUC in monkeys given a 10 mg/kg i.v. dose of PFHxA was only slightly lower in females than in males (75 vs. 84 mg-h/L), suggesting no significant sex difference in nonhuman primates.

PFHxA is resistant to metabolic transformation, and urinary excretion is the main elimination route, followed by feces (Gannon et al., 2011; Iwai, 2011; Chengelis et al., 2009a).

### 3.1.1 Absorption

Absorption is rapid in rodents and monkeys (Iwabuchi et al., 2017; Gannon et al., 2011; Chengelis et al., 2009a). PFHxA was extensively absorbed with an average time to reach maximum concentration (T_max)_ of 1 hour in Sprague-Dawley rats given 26-day repeated gavage doses of 50, 150 or 300 mg PFHxA/kg (Chengelis et al., 2009a). After gavage at 2 or 100 mg [1-^14^C]PFHxA/kg using a single dose or 14 daily consecutive doses, Gannon et al. (2011) also observed a short T_max_ of 30 and 15 minutes, respectively, in male and female Sprague-Dawley rats. Similarly, rapid absorption was also observed in CD-1 mice (Gannon et al., 2011). For female rats and male and female mice, PFHxA absorption does not appear to be saturated between 2 and 100 mg/kg as suggested by dose normalized AUC_0→168_ hour, but the data in male rats indicate either a 25% reduction in absorption or a corresponding increase in PFHxA clearance between these two dose levels (Gannon et al., 2011; Chengelis et al., 2009a).

In a recent PK study by Dzierlenga et al. (2019), Sprague-Dawley rats were given PFHxA, by i.v. injection (40 mg/kg) or gavage (40, 80, and 160 mg/kg). Besides collection of blood samples to evaluate the time course of plasma PFHxA for each dose and route, liver, kidney, and brain samples were collected to determine the distributions of PFHxA in tissues following 80 mg/kg gavage dose. A two-compartmental model was used to evaluate the PK profiles. The estimated oral bioavailability for PFHxA was >100% (Dzierlenga et al., 2019); this result simply could reflect experimental and analytical uncertainty in estimating the serum concentration AUC from intravenous versus oral exposure, but also might be due to increased reabsorption from the intestinal lumen by intestinal transporters of material excreted in the bile. The data indicate that T_max_ increased slightly but not significantly with increasing oral PFHxA dose levels for both sexes. For instance, T_max_ increased from 0.668 ± 0.154 to 0.890 ± 0.134 hour (mean ± standard error) and from 0.529 ± 0.184 to 0.695 ± 0.14 hour with increased gavage doses of PFHxA for male and female rats, respectively (Dzierlenga et al., 2019).

### 3.1.2 Distribution

PFHxA has an aqueous solubility of 15.7 g/L (Zhou et al., 2010). Computational chemistry predictions conclude that PFHxA and its salts have a pK_a_ ≤ 0 (Rayne and Forest, 2010), so it likely exists exclusively in anionic form at physiological pH (Russell et al., 2013). Therefore, it is relatively water soluble, but limited data are available to examine its distribution to various organs and tissues upon exposure in mammalian systems (Russell et al., 2013; Gannon et al., 2011). The largest concentrations were found in liver, skin, heart, lung, and kidney and concentrations peaked within hours (Iwabuchi et al., 2017; Gannon et al., 2011). For example, Gannon et al. (2011) reported heart, kidneys, liver, and lungs had detectable but not quantifiable concentrations of PFHxA at 24 hours in rats dosed with 100 mg/kg (Gannon et al., 2011). Similarly, the highest uptake concentrations occurred in the liver and femur (10 ± 2% and 5 ± 1% of the injected dose, respectively), in male CD-1 mice (Burkemper et al., 2017). As described in detail below, the volume of distribution (V_d_) was generally similar (within a factor of three) among male and female mice, rats, and monkeys (Russell et al., 2013).

#### Distribution in Animal (Rats, Mice, and Monkeys) and In Vitro Studies

Chengelis et al. (2009a) gave both Sprague Dawley rats and cynomolgus monkeys (3/sex) PFHxA (10 mg/kg) via a single i.v. injection to determine PFHxA PK using noncompartmental analysis. In monkeys they observed a distribution phase of 8 hours and an apparent V_d_ of 0.77 and 0.35 L/kg in males and females, respectively. In male and female rats, V_d_ was reported as 0.18 and 0.47 L/kg, respectively, and the distribution phase after gavage dosing was about 1–2 hours in both sexes. Serum concentrations of PFHxA were up to 17-fold higher for male than female rats after i.v. dosing. In a separate experiment male and female Sprague-Dawley rats were given oral gavage doses of 50, 150, or 300 mg/kg/d PFHxA for 25 days (6 rats/sex/dose) and the PK evaluated on the first and last day of dosing. The AUC after oral dosing was approximately 4fold higher in males than females given a 50 mg/kg gavage dose on both day 1 and day 25. The half-life in males, however, was only 2.5 times greater than females after i.v. dosing and was similar to that in females after oral dosing. Together these lead to the conclusion of higher V_d_ for females than for males.

Using a one-compartment model, Iwabuchi et al. (2017) evaluated the distribution of PFHxA and other PFAAs (PFOA, PFOS and perfluorononanoic acid, [PFNA]) in multiple tissues (brain, heart, liver, spleen, kidney, whole blood, and serum) in 6-week-old male Wistar rats. The rats were given a single oral dose or 1- and 3-month exposures in drinking water. For the single oral dose, rats were given drinking water containing a mixture of PFAAs by gavage (PFHxA, PFOA, PFOS: 100 μg/kg body weight [BW], PFNA: 50 μg/kg BW). Although the estimated T_max_ for PFHxA was 1 hour for all tissues, the T_max_ for other PFAAs was 12 hours in the tissues except the brain (72 h) and whole blood (24 h), indicating PFHxA was distributed rapidly throughout the body. Peak concentrations occurred between 15 minutes and 1 hour after dosing, depending on the tissue. Of examined tissues, the highest concentrations of PFHxA were found in the serum and kidney, equivalent to 7.9% and 7.1% of the administered PFHxA, respectively. Note that the peak concentrations measured in liver and brain were roughly 40% (at 15 minutes) and 1.5% (at 1 hour) of the corresponding peak serum levels (4.6% and 0.027% of administered PFHxA dose), respectively. The earlier peak in liver concentration is likely due to initial delivery there from oral absorption, although the results show low delivery to the brain.

Dzierlenga et al. (2019) measured levels of PFHxA in rat liver, kidney and brain over 12 hours following an 80 mg/kg oral gavage dose. In general tissue distribution was rapid, with peak concentration occurring at 0.5 hours (first time-point) in male rat liver and kidney or 1 hour (second time-point) in male rat brain and in female rat liver, kidney, and brain. The concentrations declined exponentially after the peak, with tissue: plasma ratios mostly remaining in a limited range. For example, in male and female rat kidney and female rat liver the tissue: plasma ratio only varied between 0.5 and 0.75, though the liver: plasma ratio varied between 1 and 0.5 in male rats, though without a clear pattern. However, the kidney: plasma ratio in female rats showed a steady increase from around 0.8 at 0.5 hours to around 1.7 at 3 hours, after which it slowly declined to around 1.4 at 12 hours (Dzierlenga et al., 2019). Since tissue: plasma ratios are generally less than 1, this result in the female rat kidney indicates a mechanism that was not active in the liver or male rats, perhaps involving active transport into the tissue.

For the 1- or 3-month exposures, rats were given a mixture of four PFAA dose levels: 0, 1, 5 and 25 μg/L in drinking water with similar intake rate across dose groups (0.072–0.077 L/kg BW-day) (Iwabuchi et al., 2017). In general, the long-term tissue concentrations of PFHxA predicted based on the data from the single-exposure studies were comparable to that measured after the 1- and 3-month exposures, suggesting that steady-state tissue levels were achieved rather quickly and the tissue distribution of PFHxA remained relatively constant over time (Iwabuchi et al., 2017).

An in vitro study using lung epithelial cells (NCI-H292) and adipocytes (3T3-L1K) made similar observations of no appreciable cellular accumulation and retention of PFHxA (Sanchez Garcia et al., 2018).

#### Distribution in Humans

The tissue distribution of PFHxA and other PFAAs were analyzed in 99 human autopsy samples (brain, liver, lung, bone, and kidney) (Pérez et al., 2013). Pérez et al. (2013) used the term “accumulation,” which in PK terminology describes a steady increase in the amount of a substance in the body tissues over an extended time while exposure continues at a relatively constant level. So, to demonstrate accumulation, one must have repeated measures of the blood or tissue concentration in an individual over a significant period of time. If the body quickly reaches a constant level (with ongoing exposure), that would not be called “accumulation.” Because the study data were collected from cadavers, they show only the tissue levels in the individuals at time of death, and thus do not actually demonstrate accumulation but simply that exposure, absorption, and distribution have occurred. These tissue concentrations could represent approximate steady-state concentrations that were achieved quickly after the start of exposure, without accumulation. More generally, these data cannot inform the specific exposure scenarios that might have occurred before the time of death, in particular the duration of exposure that was required to reach the observed concentrations.

Pérez et al. (2013) found PFHxA to be the main PFAA compound in the brain (mean = 180 ng/g tissue weight, median = 141 ng/g). PFHxA was detected in all collected tissue types at levels ranging from below the detection limit to an observed concentration of 569 ng/g in the lung. These observations generally demonstrate the distribution of short-chain PFAAs like PFHxA, for which the mean (or median) concentration ranged from 5.6 ng/g (2.7 ng/g) tissue in the kidney to 180 ng/g (141 ng/g) in the brain. The liver and lung had tissue levels somewhat below that in the brain but within the same range, with mean (or median) levels of 115 ng/g (68.3 ng/g) and 50.1 ng/g (207 ng/g), respectively.

Considering the relatively rapid elimination of PFHxA in humans, the high levels reported by Pérez et al. (2013) for brain, liver and lung are surprising. Abraham et al. (2021) found much lower levels of PFBA in human tissues than Pérez et al. (2013) and attributed the discrepancy to issues in the analytic chemistry. Sanan and Magnuson (2020) describe analytic issues that can impact a broad range of PFAS, including PFHxA. Multiple PFAS may co-elute from chromatographic separation, so the measurements attributed to PFHxA by Pérez et al. (2013) may reflect multiple PFAS, with PFHxA being only a small fraction of the total. Resolution of this issue is beyond the scope of this review. Pérez et al. (2013) describes what appear to be good quality control methods and their results are reported here for completeness but are not used in the quantitative dosimetric analyses presented later.

Because blood plasma concentrations could not be evaluated in the cadavers, the data of Pérez et al. (2013) lack this component of total PFHxA body burden. Plasma is a small fraction of total body mass (~ 4% in humans), but due to PFHxA’s substantial binding to serum proteins (>99% bound to serum albumin (Bischel et al., 2011)) it will carry a disproportionate amount of the PFHxA. For example, if the overall volume of distribution in humans is 0.5 L/kg, plasma will then contain about 8% of the PFHxA.

Fàbrega et al. (2015) attempted to estimate tissue: blood partition coefficients (PCs) for PFHxA using the data of Pérez et al. (2013). Because Pérez et al. (2013) did not measure or report blood concentrations, Fàbrega et al. (2015) used the mean blood concentration reported 4 years earlier for residents of the same county (Ericson et al., 2007). The resulting set of PCs ranged from 6 (unitless ratio) in the kidney to 202 in the brain, indicating a V_d_ in the human body around 40 L/kg or higher.

Zhang et al. (2013a) evaluated the distribution of several PFAS including PFHxA in matched samples of maternal blood, cord blood, placenta, and amniotic fluid among Chinese women. Only 45% of maternal blood samples were above the limit of quantitation (LOQ), with a mean concentration of 0.07 ng/mL, although 87% of cord blood samples were above the LOQ, with a mean of 0.21 ng/mL PFHxA. Only 17% of placenta samples were above the LOQ (mean concentration 0.04 ng/mL) and 45% of amniotic fluid samples (mean concentration 0.19 ng/mL). The authors urge caution in interpreting their results because recovery of PFHxA from test samples was more variable than for most other PFAAs. These data do show, however, that PFHxA distributes into the fetus during pregnancy.

More recently, Li et al. (2020) evaluated the transplacental transfer of multiple PFAS, including PFHxA, in preterm versus full-term births, and evaluated for correlation with the expression of nine placental transporters. The transplacental transfer efficiency (TTE) was calculated as the ratio of PFAS concentration in cord serum, collected at the time of birth, to the concentration in maternal serum collected within 1 week of (prior to) birth. The median TTE for preterm births was 0.8, with first and third quartiles of 0.5 and 1.17, respectively (n = 27), hence the distribution in the preterm fetus was slightly less than but not significantly different from 1. This contrasts with PFDA, for example, for which the median TTE was 0.23 and the third quartile 0.29, indicating that the placenta limited distribution of PFDA to the fetus much more so than PFHxA. In full-term births the median TTE for PFHxA was 2.26 (Q1 = 0.88, Q3 = 5.30, n = 88), which is exceptionally high compared to most other PFAS for which the median TTE ranged between 0.35 (PFDA) and 1.32. Only PFTeDA had a median full-term TTE nearly as high as PFHxA, i.e., 1.84. The authors conjectured that the general shift to higher TTE in full-term pregnancies may be due to loss of placental integrity as a barrier (Li et al., 2020), but for most PFAS this is a shift from a median value below one to a value that is higher but still less than or close to one. In the case of PFHxA these results do not indicate a significant placental barrier for the preterm fetus and an elevated transfer at full term. The TTE was not significantly correlated with any of the transporters analyzed. The p-value for association with equilibrative nucleoside transporter (ENT1) was 0.054, indicating some possibility for its role, but with a negative correlation coefficient. There was a non-significant but positive correlation between the TTE and p-glycoprotein (MDR1), which had a significant positive association with other PFAS (Li et al., 2020). So, there is no clear evidence or explanation for why PFHxA would be elevated in full-term cord blood compared to maternal blood, but it seems possible that active transport could play a role in some individuals.

The partitioning of PFHxA and 15 perfluoroalkyl substances (C6–C11) between plasma and blood cells was investigated using blood samples collected from human subjects (n = 60) (Jin et al., 2016). The results showed that although the estimated mass fraction in plasma generally increased with the carbon chain length, PFHxA appeared to have lowest mass fraction in plasma (0.24) as compared with other PFAA chemicals (0.49 to 0.95). In a study population of 61 adults in Norway, Poothong et al. (2017) also found that although PFHxA was detected in 100% of the whole blood samples, it was not detected in serum or plasma. Given the strong partitioning to whole blood (perhaps due to partitioning into blood cells), the whole blood, rather than serum or plasma, was suggested as a better blood matrix for assessing PFHxA exposure (Poothong et al., 2017).

#### Synthesis of Distribution Across Species

In contrast to the estimated PCs of Fàbrega et al. (2015), Chengelis et al. (2009a) estimated V_d_ of 0.18 and 0.47 L/kg, respectively, in male and in female rats. For monkeys, the individual estimates of V_d_ Chengelis et al. (2009a) reported varied widely for each sex; for example, the coefficient of variation among the three females was 74%. Therefore, EPA recalculated male and female values for this analysis from the mean values of AUC_0–∞_ and the beta-phase elimination constant, K_el_:

V_d_ = dose / [ mean ( AUC_0 − ∞_ ) × mean ( K_el_ ) ] . (3-1)

The resulting values of V_d_ were 0.77 L/kg and 0.35 L/kg for male and female monkeys, respectively. Although the reported values for rats and these re-estimated values for monkeys were within similar ranges, spanning less than a factor of five, the difference between males and females of each species is larger than expected. The underlying data indicate significant PK differences between males and females of each species.

The average V_d_ for rats (0.33 L/kg) is only 40% lower than the average for monkeys (0.56 L/kg), a modest species difference that could occur due to differences in the relative concentration of binding proteins and phospholipids in blood (e.g., albumin) versus the rest of body (Sanchez Garcia et al., 2018). Partitioning or distribution is primarily a function of the physicochemical properties of a tissue versus blood (binding site content and phospholipid concentration being significant components for PFAS) and are typically similar across mammalian species, not differing by orders of magnitude as suggested by the difference between the results of Fàbrega et al. (2015) for humans and the animal PC data. This raises a significant question about reasons for the apparent disparity. EPA is unaware of a specific mechanism that could explain this discrepancy, particularly one that differs between monkeys and humans to such a large extent but not between monkeys and rats.

Therefore, the most likely explanation for the differences in the PCs estimated by Fàbrega et al. (2015) are an artifact of combining data from nonmatched human samples Pérez et al. (2013) whereas Ericson et al. (2007) collected data over several years (e.g., due to a change in PFHxA exposure in that population across those times). Thus, these results are considered too uncertain for further analysis of human pharmacokinetics. Instead, the V_d_ estimated for male and female monkeys by Chengelis et al. (2009a) is assumed to provide the best estimates for men and women, respectively, given the biochemical properties of tissues that determine the relative affinity for PFHxA in tissue versus blood are more similar between humans and a nonhuman primate than between humans and rats or mice. Because the V_d_ in monkeys is similar to that in rats (see details above, Distribution in Animals) and an assumption of similar partitioning in humans versus other mammals has been successfully used for many PBPK models, this assumption is considered modest with minimal associated uncertainty.

A generally accepted assumption in pharmacokinetics is that renal clearance (via glomerular filtration) is limited to the fraction unbound in plasma (Janků, 1993). PFAS accumulation in tissues appears to correlate with phospholipid binding and content and like lipids the relative distribution of phospholipids, albumin, and other binding sites is not expected to differ by orders of magnitude between humans and other animals (Sanchez Garcia et al., 2018). Some evidence suggests plasma protein binding (e.g., serum albumin) could also play a role in PFHxA pharmacokinetics. A study by D’eon et al. (2010) evaluated the molecular interactions of PFHxA and PFOA with human serum albumin (HSA) using nuclear magnetic resonance spectroscopy. They found the interaction of both PFHxA and PFOA with HSA—assessed based on data for selected HSA ligands including oleic acid, phenylbutazone, and ibuprofen—could affect its pharmacokinetics.

Organic anion transporters, a family of transmembrane proteins, had been suggested to play a role in the renal reabsorption of PFAAs (Kudo, 2015; Weaver et al., 2010) (see further discussion below for rat studies). Weaver et al. (2010) found that renal transport of PFAAs with different chain lengths (C2–C18) could occur via specific transporters (Oat1, Oat2, Oat3, Urat1, and Oatp1a1) that were differentially located in the basolateral membrane and apical membrane in rats (Chinese hamster ovary cell line and kidney RNA from Sprague-Dawley rats). Although PFHxA was capable of inhibiting Oat1-mediated transport of p-aminohippurate, the model substrate used for PFAA transport tests, the quantitative role of organic anion transporters in PFHxA PK remains uncertain due to the rapid elimination kinetics of PFHxA (Weaver et al., 2010). The role of Oatp1a1 and its regulation by sex hormones is discussed at further length below (Rat Studies).

On the other hand, although Bischel et al. (2011) measured the binding of PFHxA to bovine serum albumin (BSA) in vitro, the measured fraction bound is 99%, which appears quantitatively inconsistent with the empirical observation that the elimination half-life is on the order of 2–3 hours in rats, for example. Renal elimination is generally predicted to be proportional to the fraction of a compound unbound in plasma (e.g., Janků and Zvára (1993)). Transporter-mediated renal resorption would only reduce elimination to a greater extent. If the binding of PFHxA to BSA is indicative of its overall fraction bound in serum and glomerular filtration could remove only 1% (i.e., the free faction) of PFHxA carried in the corresponding serum flow, the elimination half-life should be much longer than is observed. Thus, although plasma protein binding could play some role in PFHxA distribution and elimination, one must be careful in quantitatively interpreting such results. Because it is reversible, protein binding could have a limited impact on distribution and elimination, despite a relatively high fraction of plasma protein binding at equilibrium. Therefore, the empirically determined distribution and elimination rates for PFHxA in various species and sexes are used rather than the rate one might predict based on albumin binding.

### 3.1.3 Metabolism

Similar to other PFAA compounds, PFHxA is not readily metabolized as evidenced by the findings that no metabolites were recovered from either the liver or urine following oral dosing of mice or rats (Gannon et al., 2011; Chengelis et al., 2009a). Although PFHxA is resistant to metabolism, fluorotelomer-alcohols and sulfonates can undergo biotransformation to form PFHxA or its glucuronide and sulfate conjugates in rodents and humans (Kabadi et al., 2018; Russell et al., 2015).

### 3.1.4 Elimination

Existing evidence has consistently suggested PFHxA has a shorter half-life than those of other longer chained PFAAs (e.g., PFOA or PFOS). For instance, approximately 80% of the administered dose of PFHxA appeared in the urine of rats 24 hours post-dosing regardless of sex following i.v. injection (Chengelis et al., 2009a). Daikin Industries recovered approximately 90% of an oral dose of 50 mg/kg PFHxA, either as a single dose or on the 14th day of dosing by 24 hours after the single or last dose in male and female rats and mice (Daikin Industries, 2009a, b). Likewise Dzierlenga et al. (2019) reported that liver and kidney concentrations peaked by 30 min in male rats and by 1 hour in female rats after gavage and decreased steadily thereafter (observations at 0.5, 1, 3, 6, 9 and 12 hours). The tissues concentrations of PFHxA tended to be very low or not quantifiable 24 hours after dosing in both sexes of mice and rats (Iwabuchi et al., 2017; Gannon et al., 2011).

The comparable weight-normalized blood elimination half-life of PFHxA across mammalian species further implies the lack of species-specific roles for renal tissue transporters, either in facilitating elimination or impeding elimination through renal resorption for PFHxA, unlike the situation for some long-chain PFAAs. Gomis et al. (2018) concluded PFHxA had a relatively short elimination half-life and the lowest bioaccumulation among the six PFAAs they evaluated based on applying a one-compartment PK model combined with PK data compiled from previous studies on male rats. In particular, the beta- or elimination-phase half-life (t_½, β_) values estimated were: PFHxA = 2.4 hours, perfluorobutane sulfonate (PFBS) = 4.7 hours, pentafluorobenzoic acid (PFBA) = 9.2 hours, ammonium 2,3,3,3-tetrafluoro-2-(heptafluoropropoxy)-propanoate (GenX) = 72 hours, PFOA = 136 hours, and PFOS = 644 hours (Gomis et al., 2018). PK model simulations from a 10-day oral experiment with a dose of 1 mg/kg-day predicted that, as compared to other PFAAs, PFHxA had the lowest serum and liver AUC levels. Likewise, Chengelis et al. (2009a) compared PFHxA dosimetry in naïve male and female rats to results after 25 days of dosing (50–300 mg/kg-day) and found no significant difference in the parameters evaluated, with the serum half-life remaining in the range of 2–3 hours.

#### Rat Studies

Iwai (2011) evaluated PFHxA excretion in Sprague-Dawley rats and CD-1 mice treated with single and multiple (4 days) oral dose(s) at 50 mg/kg of [^14^C] ammonium perfluorohexanoate (APFHx). Urine and feces samples were collected for 0–6 hours (urine only) and 6–24 hours and then followed 24-hour intervals until 72 hours after dosing. Expired air was collected over 0–24 and 24–48 hours following oral exposure. For the single dose administration in rats, 97%–100% of administered PFHxA dose was recovered within 24 hours with urine as the major route of elimination (73.0%–90.2%), followed by feces (7.0%–15.5% of the administered dose). No appreciable PFHxA was found in expired air. Two percent of the dose remained in the gastrointestinal tract and carcass. Comparable findings were observed with the multiple oral dose administration (14 daily doses) scenarios (Iwai, 2011).

Chengelis et al. (2009a) reported the terminal half-life of PFHxA in serum was about 2.4-fold shorter for female Sprague-Dawley rats than for male rats (0.42 hours compared to 1.0 hour) with a single dose of 10 mg/kg i.v. injection. Likewise, Gannon et al. (2011) reported elimination half-lives for PFHxA of 1.7 and 1.5 hours in male rats and 0.5 and 0.7 hours in female rats for doses of 2 and 100 mg/kg, respectively. On the other hand, after repeated oral administration (50–300 mg/kg-day) of PFHxA, Chengelis et al. (2009a) found the serum terminal half-life of PFHxA was generally in the range of 2–3 hours regardless of sex. Comparable urinary elimination half-lives following single 10 mg/kg i.v. were also observed (males: 2.1 hours; females 2.5 hours) (Chengelis et al., 2009a). It is unclear why Chengelis et al. (2009a) obtained different half-lives for males versus females from some of their results, but not in others. Evaluation of the half-life from any PK data set depends on the study design, especially the number and spacing of data points relative to the half-life, the type of PK analysis done, and analytic sensitivity. EPA analyzed PFHxA half-lives that combined data across studies to obtain sex-specific values, described in Section 5.2.1 (Approach for Animal-Human Extrapolation of PFHxA Dosimetry).

As noted above, Daikin Industries evaluated urinary and fecal excretion in Sprague-Dawley rats after 50 mg/kg oral doses for 1 or 14 days (Daikin Industries, 2009a, b). The elimination pattern is consistent with other studies described here, with approximately 90% of the dose recovered in feces and urine by 24 hours. Because excretion was only evaluated at 6 hours (urine only), 24 hours, and multiple days thereafter, these specific studies are not considered quantitatively informative for evaluation of half-life or clearance.

Russell et al. (2015) conducted PK modeling analysis of 3,3,4,4,5,5,6,6,7,7,8,8,8-Tridecafluorooctanol (6:2 FTOH) inhalation (0.5 or 5 ppm) in rats, including its metabolite PFHxA, as described above. The estimated PFHxA half-lives were 1.3 and 0.5 hours in male and female rats, respectively, from single-day exposures, with the estimated yield of PFHxA ranging from 0.5 mol% to 1.9 mol%. The model assumes, however, that the yield of PFHxA from 6:2 FTOH is independent of time. This apparent time-dependence in the half-life could be an artifact of that assumption if induction of metabolism during the dosing period leads to a higher yield with later times. A more comprehensive multiday PK analysis would be needed to demonstrate time-dependent PFHxA clearance unequivocally. Using a noncompartmental PK analysis Kabadi et al. (2018) reanalyzed the 1-day data of Russell et al. (2015) and obtained the same half-life values (1.3 and 0.5 hours in males and females).

A recent study by Dzierlenga et al. (2019) and NTP (2017) showed no apparent pattern in t_½, β_ among the i.v. (40 mg/kg) and two lower oral doses (40 and 80 mg/kg) for each sex (ranges 5.74–9.3 hours for male rats and 2.3–7.3 hours for female rats), which likely reflects experimental variability. The t_½, β_ for the 160 mg/kg oral dose appeared higher than the other three measurements (13.7 ± 14.2 and 12.2 ± 23.6 hours [mean ± standard error of the mean] for males and females, respectively), but a loss of dose-concordance occurred among the PK data starting at 6 hours (i.e., the serum concentrations were similar for all dose levels at 6 hours and beyond). Also, the data at the last time point (24 hours) varied considerably, resulting in large uncertainty in the estimated terminal half-lives (Dzierlenga et al., 2019).

Similar to the elimination half-life in male Sprague-Dawley rats, the estimated serum elimination half-life of PFHxA in male Wistar rats (6 weeks old) was about 2.6 hours for a single dose of 100 μg/kg BW or 2.9 hours for exposures in drinking water of 1 or 3 months (Iwabuchi et al., 2017). Using a single-compartment PK model with an elimination constant defined as k_e_ = ln(2)/t_1/2_ and obtained from a single-day exposure, the predicted serum concentration after 1 and 3 months of exposure was only 10% higher and 15% lower than the measured concentrations at these time points, respectively. Thus, a systematic change in the half-life or clearance with repeated dosing is not apparent.

In support of the empirical estimates of half-lives described above indicating sex-specific differences in the elimination of PFHxA, the differences can be explained (at least in part) based on available mechanistic information. Specifically, sex hormone-dependent differences occur in expression of transporter proteins in the rat kidney. In rats, kidney Oatp1a1 is expressed at the apical membrane of the proximal tubule (Bergwerk et al., 1996) and mediates sodium-independent transport of thyroid hormones, cholesterol-derived molecules (Hata et al., 2003; Shitara et al., 2002), and PFAS (Han et al., 2012; Yang et al., 2010). In male rats, Oatp1a1 mRNA expression was 2.5-fold greater than in females, undetectable in castrated rats, and inducible in male rats by treatment with estradiol (Kudo et al., 2002).

A separate study (Lu et al., 1996) reported the same sex hormone-dependent effect on Oatp1a1 mRNA expression in castrated males or ovariectomized females treated with testosterone or estradiol. Further, Gotoh et al. (2002) confirmed that Oatp1a1 protein levels were undetectable from female rat kidney and highly expressed in male rat kidney. Because these hormone-dependent transporters are predicted to increase renal resorption of PFHxA in male rats, the implication is that PFAS elimination in female rats should be more rapid compared with male rats. Not all the results above match this expectation, which could reflect a limited activity of the renal transporters toward PFHxA, or simply aspects of experimental design and sampling that measure the PK parameters better in some studies than others. The empirical results of Chengelis et al. (2009a) and Dzierlenga et al. (2019), however, are consistent with this prediction: higher clearance and shorter half-lives in female rats compared to male rats.

Some evidence also suggests the affinity for Oatp1a1 depends on PFAS chain length. Specifically, Yang et al. (2009) examined the role of PFAS (C4–C12) in inhibiting the uptake of estrone-3-sulfate (E3S3S) using Oatp1a1-expressing Chinese hamster ovary cells. They showed the level of inhibition of E3S uptake increased as the chain length increased; for example, PFHxA inhibited E3SS uptake with an inhibition constant (K_i_) of 1,858 µM, as compared with 84 µM for PFOA. This high K_i_ for PFHxA (i.e., the concentration required to inhibit one-half the Oatp1a1 activity, 584 µg/mL) indicates a low affinity of PFHxA for the transporter and thus leads to predictions of a low impact of Oatp1a1 expression on PFHxA elimination kinetics, contrary to the empirical PK data discussed above. Chengelis et al. (2009a) clearly showed more rapid elimination in female rats versus male rats at serum concentrations below 40 µg/mL, that is, an order of magnitude or more below the K_i_. As most of the water is resorbed from the renal filtrate, however, the concentration of PFHxA in the remaining fluid will increase proportionately. Thus, the PFHxA concentrations in the proximal tubule of these rats (where Oatp1a1 is expressed) could be high enough for significant transporter activity, but below the level of saturation.

Collectively, the evidence provides a biologically plausible explanation for the observed sex-specific PFHxA elimination in rats (i.e., the 2- to 3-fold longer half-life in male versus female rats), although uncertainties remain (Han et al., 2012; Gannon et al., 2011; Chengelis et al., 2009b). Most notably, whether this apparent sex difference in re-uptake exists in humans or in species other than rats is unclear. Organic-anion transporters are known to be under hormonal regulation in rat and mouse kidney, with gender-specific differences in their expression likely regulated by sex-hormone receptors. Some evidence suggests similar sex-related differences in humans (Sabolić et al., 2007). Kudo et al. (2001) demonstrated that the sex-related difference in PFOA elimination in rats was abolished when male rats were castrated, increasing to match that in females, and that its elimination was reduced in both females and castrated males treated with testosterone. This demonstration of hormone-related elimination for PFOA and observations of sex differences in the elimination of other PFAS such as PFNA, PFOA, and PFBS (Chengelis et al., 2009a; Kudo et al., 2001) suggest this is a common underlying mechanism for PFAS elimination.

#### Mouse Studies

As stated above (Elimination, Rat Studies), Iwai (2011) evaluated PFHxA excretion in CD-1 mice after single and 14-day oral exposures. Results were similar for single and multiple dose administrations. After multiple doses, >95% of the administered PFHxA was recovered within 24 hours with urine as the major route of elimination (77.8%–83.4%), followed by feces (9.6%–12.9% of the administered dose). Only 0.6%−0.9% remained in the gastrointestinal tract and carcass. Gannon et al. (2011) also evaluated PFHxA PK in mice but state they did not report half-lives in mice because the data showed a biphasic clearance pattern that precluded use of the standard noncompartmental modeling.

As noted above, Daikin Industries evaluated urinary and fecal excretion in CD-1 mice after 50 mg/kg oral doses for 1 or 14 days (Daikin Industries, 2009a, b). The elimination pattern is consistent with Iwai (2011), with approximately 90% of the dose recovered in the urine and feces (total) after 24 hours. Because excretion was only evaluated at 6 hours (urine only), 24 hours, and multiple days after the PFHxA dosing ended, however, the studies cited are not considered quantitatively informative for evaluation of half-life or clearance.

Daikin Industries (2010) evaluated the time-course of PFHxA in female Crl:CD(1CR) mouse plasma after single oral gavage doses of 35, 175, and 350 mg/kg, with concentrations measured at 0.5, 2, 4, 6, 8, and 24 hours. The estimated half-life was between 0.9 and 1.2 hours for the three dose groups but lacked a dose-dependent pattern. However, the C_max_/dose was 2.76, 1.88, and 1.30 kg/L for the 35, 175, and 350 mg/kg doses, respectively, indicating saturation of absorption with higher doses. The AUC_0–∞_/dose was not dose-dependent, although it varied between 5.1 and 6.5 kg-h/L, indicating that clearance was not dose-dependent.

The plasma time-course data from Gannon et al. (2011) and Daikin Industries (2010) were reevaluated by EPA as described with the derivation of the HED in Section 5.2.1 (Approach for Animal-Human Extrapolation of PFHxA Dosimetry) and Appendix C to obtain overall pharmacokinetic parameters.

#### Monkey Studies

In the study on cynomolgus monkeys by Chengelis et al. (2009a), three males and three females received 10 mg/kg PFHxA by i.v. injection. The mean clearance was nearly the same in both sexes (0.122 L/h-kg in males and 0.136 L/h-kg in females), but the estimated half-life appeared longer in males (5.3 ± 2.5 hours) than in females (2.4 ± 1.7 hours) with a corresponding apparent difference in V_d_ (0.989 L/kg in males and 0.474 L/kg in females). The similarity of the clearance values and the nearly identical serum values for males and females after the first 4 hours suggest no striking sex differences in the pharmacokinetics of PFHxA in monkeys.

#### Human Studies

No controlled exposure PK studies of PFHxA elimination in humans are available but Russell et al. (2013) applied PK analysis to biomonitoring data from Nilsson et al. (2013) to estimate the half-life of PFHxA in humans. Specifically, Russell et al. (2013) estimated the apparent half-life of PFHxA in humans by analyzing biomonitoring data collected from professional ski wax technicians and then compared the human estimates of PFHxA elimination to that for mice, rats, and monkeys. For the human monitoring study, blood samples (n = 94) were collected from male professional ski wax technicians (n = 11) and analyzed for PFHxA in plasma and serum. (Individual data for eight of the technicians are shown in Appendix C.2; complete data are available as the supplemental information for Nilsson et al. (2013)). Personal and area air concentration monitoring of the ski wax subjects and facilities demonstrated both the metabolic precursor, 6:2 FTOH, and PFHxA were present in all locations, but the arithmetic mean concentration of 6:2 FTOH ranged from over 100 times higher than PFHxA to almost 100 times lower, across the monitoring locations. A one-compartment model with first-order kinetics was used for PK analyses. The estimated geometric mean half-life of PFHxA was 32 days with a range of 14–49 days in the studied population (Russell et al., 2013). PFHxA plasma concentrations declined below the plasma detection limit of 0.05 ng/mL within a period of 2–4 months after exposure ceased, reflecting the relatively rapid elimination rate of PFHxA. In contrast, the half-life of PFHxS in humans was estimated to range from 5 to 9 years (Olsen et al., 2007).

Analysis by Luz et al. (2019) found no significant species- or sex-related differences in the elimination kinetics of PFHxA. The PK analysis, however, is attributed to a meeting abstract (Buck and Gannon, 2017) and provides no details of the methods the authors used. The text of Luz et al. (2019) indicates the analysis of Buck and Gannon (2017) used data from only 3 of the 11 subjects of Nilsson et al. (2013), specifically the 3 with the most rapid elimination, reducing the extent to which the conclusion can be reliably extrapolated to the population as a whole. Luz et al. (2019) state slower apparent elimination could occur in some subjects because of ongoing exposure. Although ongoing exposure could cause this effect, it is also possible that elimination in some individuals is slower than others due to interindividual variability. In the absence of independent evidence that ongoing exposure occurred in other human subjects of Nilsson et al. (2013) who were excluded in this later analysis, EPA does not consider basing conclusions on human elimination on only the three individuals who had the most rapid elimination appropriate.

EPA examined the data of Nilsson et al. (2013), and the observed seasonal variation appears to show a longer systemic period of exposure (when blood levels are elevated versus. Declining) for some individuals than others. Also, the data set includes samples with concentrations below the limit of detection (LOD) that should be treated with an appropriate statistical model to account for the censoring of these data. Finally, only the data collected encompassing the 2007–2008 ski season, during which only 8 of the 11 technicians were sampled, includes post-exposure samples needed to quantify elimination. A detailed description of EPA’s analysis of the eight technicians sampled during the 2007–2008 season is provided in Appendix C.2. Briefly, each ski-wax technician in the study was presumed to have a constant rate of exposure up to a date that is different for each individual when exposure stopped, and elimination began. Specifically, we used a one-compartment i.v.-infusion model to fit the data:

C ( t ) = { (A)/(tinf ⋅ k e) ⋅ ( 1 − e^− k e ⋅ t^ ) , if t ≤ tinf (A)/(tinf ⋅ k e) ⋅ ( 1 − e^− k e ⋅ tinf^ ) ⋅ e^− k e ⋅ ( t − tinf )^ , if t > tinf (3-2)

Where A = dose/V_d_, tinf is the time period of exposure (treated as an infusion), and ke is the elimination rate. The model is analyzed through hierarchical Bayesian analysis, with A and tinf estimated independently for each individual technician although the technician-level ke is drawn from a population-level distribution. Note blood concentrations were measured only once a month and no other data on exposure is available. Thus, although the model clearly simplifies the exposure estimation, estimating a larger number of parameters reliably would not be possible. As such, the model allows for estimating variation among individuals without subjectively selecting a subset of the technicians for analysis. The resulting distribution of ke had a mean (90% confidence interval, CI) of 0.00252 (0.00136–0.00477) h^−1^. Using an average V_d_ of 0.7315 L/kg (731.5 mL/kg) for male and female monkeys from Chengelis et al. (2009a), the resulting mean for human clearance is CL = V_d_·ke = 1.84 mL/kg-h. Given the expected similarity of V_d_ across mammalian species, EPA considers the average value estimated for rats (0.33 L/kg) to be a reasonable lower bound for humans and the highest value reported by Chengelis et al. (2009a) for an individual (male) monkey (1.54 L/kg) to be a reasonable upper bound. Combining these with the 90% CI for ke (0.00136–0.00477 h^−1^) yields a possible range for human clearance of 0.45–7.35 mL/kg-h, a range of 16-fold from 4-fold above to 4-fold below the estimated mean.

Xiao et al. (2011) measured the serum concentrations of 10 PFAA chemicals in 227 nonoccupationally exposed individuals aged 0.3–90 years (133 males and 94 females) in China. Significant positive correlations were observed between age and serum levels of PFAA chemicals except for PFBS, PFHpA, and PFHxA. Spearman correlation coefficients between age and serum PFHxA were 0.20, −0.02, and 0.08 for males, females, and the combined data, respectively. Collectively, the findings indicated no age-related accumulation of PFHxA in human bodies, which is consistent with the relatively short half-life.

### 3.1.5 PBPK Models

No PBPK model is available for PFHxA in rats, mice, or monkeys. Fàbrega et al. (2015) described a PBPK model for multiple PFAS in humans, including PFHxA. However, Fàbrega et al. (2015) state two key parameters that determine the rate of resorption from glomerular filtrate in the kidney were identified using the data from the Ericson et al. (2007) epidemiological survey of PFAS exposure in residents of Catalonia, Spain. Because PFHxA was not detected in any individuals sampled by Ericson et al. (2007), EPA does not consider it possible to reliably identify elimination parameters from that data set. Further, the individual exposure or elimination data needed to associate the blood concentrations of Ericson et al. (2007) with urinary clearance rates are not reported in either paper. Thus, uniquely identifying two parameters with a single combination of average PFHxA exposure and average blood concentration is impossible. Finally, as described above (Distribution, Distribution in Humans), the tissue: blood partition coefficients Fàbrega et al. (2015) estimated are not considered suitable for the purposes of this assessment due to the 4+-year lag in measurements between collection of the blood samples and the tissue samples and because they are inconsistent with data on PFHxA distribution in other species, including monkeys. Thus, the PBPK model of Fàbrega et al. (2015) is not considered sufficiently suitable for use in this assessment.

### 3.1.6 Summary

The PFHxA elimination half-lives and clearance values reported in studies are important for interpreting and quantifying health outcomes potentially associated with PFHxA exposure. The most notable finding was the apparent sex-specific PK differences between male and female mice and rats where female rodents eliminate PFHxA 2–3 times faster than males (see Table 3-1). Although monkeys have half-lives and clearance values in the same range as mice and rats, the clearance in female monkeys is only 11% faster than in males. This indicates that the significant sex differences observed in rodents does not appear to apply to primates. Humans have a much longer serum elimination half-life (EPA estimate: 275 hours) than rodents and monkeys (2–7 hours). The difference could be a consequence of species differences in the expression or activity of the renal transporters that reabsorb PFAS, but this has not been demonstrated. All available PK evidence is summarized below in Table 3-1.

According to EPA’s BW^0.75^ guidelines (U.S. EPA, 2011), use of chemical-specific data for dosimetric extrapolation such as the PFHxA-specific data described above is preferable to the default method of BW^0.75^ scaling. That is the case here. For example, using the standard species BWs of 0.25 kg in rats and 80 kg in humans, the half-life in humans is predicted to be 4.2 times greater than rats. Given half-lives in the range of 0.4–14 hours among male and female rats (see Table 3-1), one would then predict half-lives of 1.6–57 hours in humans, 20–200 times lower than the range estimated by Russell et al. (2013) and 10–100 times lower than the range estimated by EPA (see Table 3-1). Thus, based on the PFHxA-specific PK data, use of BW^0.75^ for dosimetric extrapolation could lead to an underprediction of human elimination by 1–2 orders of magnitude. Therefore, use of BW^0.75^ as an alternative means of extrapolation is not considered further for PFHxA, and the preferred, data-driven approach will be used for the dosimetric extrapolation.

Table 3-1 Summary of PK evidence for PFHxA

Species/sex | Study design (dose) | Elimination halflife (beta) (h) | AUC/dose (kg-h/L) | Clearance (mL/h-kg) | Volume of distribution (mL/kg) | Reference
Rats
Male | Single i.v. dose (10 mg/kg) | 1.0 | 8.7 | 116 | 175 | Chengelis et al. (2009a)
Male | Single oral dose (50 mg/kg) | 2.2 | 10.0 | NR | NR | Chengelis et al. (2009a)
Male | Single oral dose (150 mg/kg) | 2.4 | 6.1 | NR | NR | Chengelis et al. (2009a)
Male | Single oral dose (300 mg/kg) | 2.5 | 8.4 | NR | NR | Chengelis et al. (2009a)
Female | Single i.v. dose (10 mg/kg) | 0.42 | 1.3 | 775 | 466 | Chengelis et al. (2009a)
Female | Single oral dose (50 mg/kg) | 2.6 | 2.4 | NR | NR | Chengelis et al. (2009a)
Female | Single oral dose (150 mg/kg) | 2.2 | 2.2 | NR | NR | Chengelis et al. (2009a)
Female | Single oral dose (300 mg/kg) | 2.1 | 3.5 | NR | NR | Chengelis et al. (2009a)
Male | Single i.v. dose (40 mg/kg) | 8.0 ± 2.2 | 7.4 ± 0.7 | 136 ± 13 | 430 ± 112 | Dzierlenga et al. (2019); NTP (2017)
Male | Single oral dose (40 mg/kg) | 9.3 ± 20.8 | 9.7 ± 1.3 | 103 ± 13 | 601 ± 470 | Dzierlenga et al. (2019); NTP (2017)
Male | Single oral dose (80 mg/kg) | 5.7 ± 4.6 | 6.6 ± 0.5 | 153 ± 11 | 496 ± 81 | Dzierlenga et al. (2019); NTP (2017)
Male | Single oral dose (160 mg/kg) | 14 ± 14 | 6.8 ± 0.6 | 147 ± 14 | 615 ± 367 | Dzierlenga et al. (2019); NTP (2017)
Female | Single i.v. dose (40 mg/kg) | 7.3 ± 2.0 | 3.1 ± 0.3 | 327 ± 33 | 223 ± 45 | Dzierlenga et al. (2019); NTP (2017)
Female | Single oral dose (40 mg/kg) | 2.3 ± 213 | 6.1 ± 1.1 | 164 ± 29 | 327 ± 149 | Dzierlenga et al. (2019); NTP (2017)
Female | Single oral dose (80 mg/kg) | 5.5 ± 2.6 | 3.2 ± 0.4 | 314 ± 39 | 560 ± 113 | Dzierlenga et al. (2019); NTP (2017)
Female | Single oral dose (160 mg/kg) | 12 ± 24 | 3.7 ± 0.5 | 274 ± 37 | 473 ± 158 | Dzierlenga et al. (2019); NTP (2017)
Male | Single oral dose (2 mg/kg) | 1.7 ± 0.6 | 8 ± 1.5 | NR | NR | Gannon et al. (2011)
Male | Single oral dose (100 mg/kg) | 1.5 ± 0.2 | 6.5 ± 1.4 | NR | NR | Gannon et al. (2011)
Female | Single oral dose (2 mg/kg) | 0.5 ± 0.1 | 2.5 ± 0.5 | NR | NR | Gannon et al. (2011)
Female | Single oral dose (100 mg/kg) | 0.7 ± 0.3 | 2.5 ± 0.7 | NR | NR | Gannon et al. (2011)
Male | Single i.v. dose (0.1 mg/kg) | 2.7 | 9.8 | NR | 400 | Iwabuchi et al. (2017)
Male | Single inhalation^a^ (0.5 ppm) | 1.3 | ND^b^ | 107 | NR | Kabadi et al. (2018)
Male | Single inhalation^a^ (5.0 ppm) | 1.3 | ND^b^ | 277 | NR | Kabadi et al. (2018)
Female | Single inhalation^a^ (0.5 ppm) | 0.5 | ND^b^ | 107 | NR | Kabadi et al. (2018)
Female | Single inhalation^a^ (5.0 ppm) | 0.5 | ND^b^ | 277 | NR | Kabadi et al. (2018)
Mice
Male | Single oral dose (2 mg/kg) | ND | 12 | NR | NR | Gannon et al. (2011)
Male | Single oral dose (100 mg/kg) | ND | 12 | NR | NR | Gannon et al. (2011)
Female | Single oral dose (2 mg/kg) | ND | 4 | NR | NR | Gannon et al. (2011)
Female | Single oral dose (100 mg/kg) | ND | 6.4 | NR | NR | Gannon et al. (2011)
Monkeys
Male | Single i.v. dose (10 mg/kg) | 5.3 ± 2.5 | 8.4 ± 1.8 | 122 ± 24 | 989 ± 579 | Chengelis et al. (2009a)
Female | Single i.v. dose (10 mg/kg) | 2.4 ± 1.7 | 7.5 ± 1.3 | 136 ± 22 | 474 ± 349 | Chengelis et al. (2009a)
Humans
Males and females | Post-exposure observation in male ski wax technicians | 768 (336–1,176) 275 (145–509) | ND | ND 1.84 (0.45–7.35) | ND | Russell et al. (2013); Current analysis

i.v. = intravenous; ND = not determined; NR = not reported.

a 6-hour inhalation exposure to 6:2 FTOH.

b Dose of PFHxA unknown.

## 3.2 NONCANCER EVIDENCE SYNTHESIS AND INTEGRATION

For each potential health effect discussed below, the synthesis describes the evidence base of available human and animal studies. The PFHxA animal literature inventory (https://public.tableau.com/profile/literature.inventory#!/vizhome/PerfluorohexanoicAcidPFHxAEvidenceMapVisualization/AnimalStudies) summarizes the evidence base on potential health effects (organized by organ or system) from the available high and medium confidence short-term, developmental, subchronic, and chronic studies in mice and rats (NTP, 2018; Klaunig et al., 2015; Iwai and Hoberman, 2014; Chengelis et al., 2009b; Loveless et al., 2009; Kirkpatrick, 2005a). These animal studies represent the primary evidence available for this PFAS, and a more detailed summarization of study methods and findings is provided in HAWC (https://hawcprd.epa.gov/assessment/100500070/). Some organs/systems for which animal data were available are summarized in the animal literature inventory (https://public.tableau.com/profile/literature.inventory#!/vizhome/PerfluorohexanoicAcidPFHxAEvidenceMapVisualization/AnimalStudies), but these data were not synthesized due to insufficient evidence to draw hazard judgments (i.e., evidence is inadequate). Specifically, for these health effects there were either few studies with null results (i.e., dermal, musculoskeletal, sensory, ocular) or few studies with sporadic findings of unclear toxicological significance (i.e., respiratory, gastrointestinal system, cardiovascular, and metabolic effects), including small changes in indirect outcome measures and other effects of unclear biological significance in isolation (e.g., decreases in cholesterol). Similarly, one low confidence cross-sectional study in general population adults in China examined the association between PFHxA exposure and adiposity (Tian et al., 2019); however, due to concern for exposure misclassification resulting from reverse causation, no judgment could be drawn (i.e., evidence is inadequate) and these data were not synthesized. Effects on body weights and survival, which had no effect or lowest effect levels at the highest administered dose in animal studies, were also not separately synthesized but were used to aid the interpretation of other potential health effects of PFHxA exposure.

### 3.2.1 Hepatic Effects

#### Human

Three epidemiological studies report on the relationship between PFHxA exposure and liver enzymes. Of these, one (Jiang et al., 2014), a cross-sectional study of pregnant women in China, was critically deficient in the confounding domain and was considered overall uninformative. There was no consideration of potential confounding in the study design and analysis. Most notably, there was no adjustment for age, which is a highly relevant potential confounder of the association. Based on these deficiencies, the study was excluded from further analysis (see Figure 3-1). The remaining studies (Liu et al., 2022; Nian et al., 2019) were cross-sectional studies in general population adults in China and were classified as medium confidence (see Figure 3-1). Liu et al. (2022) reported positive associations (i.e., higher liver enzyme levels with higher PFHxA exposure) for serum albumin (p < 0.05) and alanine aminotransferase (ALT) and alkaline phosphatase (ALP) (not statistically significant), but no association with aspartate aminotransferase (AST), total protein, or γ-glutamyl transferase (GGT). Nian et al. (2019) did not observe an association between PFHxA levels and ALT, AST, total protein, ALP, GGT, total bilirubin, or cholinesterase. Sensitivity was a concern in both studies due to limited exposure contrast (i.e., likely insufficient variability in exposure levels to detect an association), which may explain the limited observed associations.

Figure 3-1 Study evaluation for human epidemiological studies reporting hepatic system findings from PFHxA exposures (full details available by clicking the HAWC link (https://hawcprd.epa.gov/summary/visual/100500123/))

Note that for N/A, critical deficiencies in confounding domains were identified and the study was judged as uninformative; thus, the remaining domains were not evaluated.

Grid graphic of study evaluation.

#### Animal

Hepatic outcomes were evaluated in multiple short-term, subchronic, or chronic studies in rats and mice (NTP, 2018; Klaunig et al., 2015; Iwai and Hoberman, 2014; Chengelis et al., 2009b; Loveless et al., 2009). Generally, studies were rated as medium or high confidence for the hepatic outcomes, but some outcome-specific considerations for study evaluation were influential on the overall confidence ratings for hepatic effects. Histopathology for Chengelis et al. (2009b) was rated low confidence because of issues related to observational bias, endpoint sensitivity and specificity, and results presentation. Results of the outcome-specific confidence evaluations are presented in Table 3-2 below, and details are available by clicking the HAWC link (https://hawcprd.epa.gov/summary/visual/100500177/).

Table 3-2 Evaluation results for animal studies assessing effects of PFHxA exposure on the hepatic system

Author (year) | Species, strain (sex) | Exposure design | Exposure route and dose range | Organ weight | Histopathology | Clinical chemistry | Peroxisomal beta oxidation
NTP (2018) | Rat, Harlan Sprague-Dawley (male and female) | Short term (28 d) | Gavage^a^; Male and female: 0, 62.5, 125, 250, 500, 1,000 mg/kg-d | ++ | ++ | ++ | NM
Chengelis et al. (2009b) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | Subchronic (90 d) | Gavage^a^; Male and female: 0, 10, 50, 200 mg/kg-d | ++ | − | ++ | −
Loveless et al. (2009) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | Subchronic (90 d) | Gavage^b^; Male and female: 0, 20, 100, 500 mg/kg-d | ++ | ++ | ++ | ++
Klaunig et al. (2015) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | 2-yr cancer bioassay | Gavage^a^; Male: 0, 2.5, 15, 100 mg/kg-d; Female: 0, 5, 30, 200 mg/kg-d | NM | ++ | ++ | NM

++ Outcome rating of high confidence; + outcome rating of medium confidence; - outcome rating of low confidence; – outcome rating of uninformative; NM, outcome not measured.

a,b Study evaluation for animal toxicological hepatic endpoints reported from studies with male and female rats receiving by gavage PFHxA^a^ or PFHxA sodium salt. ^b^ Study evaluation details for all outcomes are available by clicking the HAWC link (https://hawcprd.epa.gov/summary/visual/100500177/).

##### Organ Weight

Overall, findings of increased liver weights after oral PFHxA or PFHxA sodium salt exposures in rats were consistent (see Figure 3-2; exposure response array link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-hepatic-effects-liver-weig/)). Relative liver weights (see Table 3-3) are generally considered more reliable than absolute liver weights because they consider large variations in body weight that could skew organ weight interpretation (Hall et al., 2012). Large variations in body weights were not observed after PFHxA exposures in male and female adult rats, and changes in both relative and absolute liver weights were similarly increased and dose responsive. Increases in relative and absolute liver weights were dose-dependently increased in all three short-term and subchronic studies. Statistically significant increases in male rat relative liver weights were observed with oral doses of ≥200–250 mg/kg-day, whereas statistically significant increases in female rats were observed only at ≥500 mg/kg-day. Specifically, in the 28-day study, relative liver weight was increased (14%) in male rats at 250 mg/kg-day, where a similar increase (15%) was observed in female rats at 500 mg/kg-day (NTP, 2018). In the subchronic studies, relative liver weights were increased (22%) at 200 mg/kg-day in males (with no change in females) in one study (Chengelis et al., 2009b), and the other study observed increases of 63% and 37% at 500 mg/kg-day in males and females, respectively (Loveless et al., 2009). Note that PFHxA effects on relative liver weights had resolved by 30 days in the recovery group (Chengelis et al., 2009b). Liver weights were not evaluated in the chronic study (Klaunig et al., 2015).

Figure 3-2 Liver weights (absolute and relative) after short-term and subchronic PFHxA exposures (full details available by clicking the HAWC link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-hepatic-effects-liver-weig/))

Chart of PFHxA effects on liver weight.

Table 3-3 Percent increase in relative liver weight due to PFHxA exposure in short-term and subchronic oral toxicity studies

Study design and reference | Dose (mg/kg-d)
Study design and reference | 2.5 | 5 | 10 | 15 | 20 | 30 | 35 | 50 | 62.5 | 100 | 125 | 175 | 200 | 250 | 500 | 1,000
28-d, female rat; (NTP, 2018) | | | | | | | | | 1 | | 2 | | | 7 | 15^*^ | 47^*^
28-d, male rat; (NTP, 2018) | | | | | | | | | 8 | | 7 | | | 14^*^ | 32^*^ | 64^*^
90-d, female rat; (Chengelis et al., 2009b) | | | 4 | | | | | 6 | | | | | 5
90-d, male rat (Chengelis et al., 2009b) | | | 1 | | | | | 1 | | | | | 22^*^
90-d, female rat (Loveless et al., 2009) | | | | | −1 | | | | | 5 | | | | | 37^*^
90-d, male rat (Loveless et al., 2009) | | | | | 0 | | | | | 11 | | | | | 63^*^

* Indicates instances where statistical significance (p < 0.05) compared to controls was reported by study authors;shaded cells represent doses not included in the individual studies.

##### Histopathology

Treatment-related increases in liver weight can result from various changes in hepatic morphology including hyperplasia of any resident liver cell type, cellular hypertrophy, inflammation, fibrosis, increase in hepatocyte size, neoplasia, congestion, or metabolic enzyme induction (Hall et al., 2012; Thoolen et al., 2010; U.S. EPA, 2002a). As shown in Table 3-4 and summarized in the HAWC link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-histopathology/), four studies evaluated liver histopathology in rats. One observed effect of PFHxA exposure was hepatocellular hypertrophy that was consistent across the short term and subchronic studies. Hepatic hypertrophy can refer to an increase in liver weight and size; an increase in hepatocyte size caused by abnormal storage of water, glycogen, lipids, or organelle proliferation; and an increase in hepatic enzyme induction (Hall et al., 2012; Thoolen et al., 2010; U.S. EPA, 2002a). Coherent with findings on liver weight, the observations of hepatocellular hypertrophy were dose-dependent and male rats were more sensitive than females. Specifically, increased hepatocellular hypertrophy was observed in adult male and female rats in the high confidence short-term (NTP, 2018) and high confidence subchronic (Loveless et al., 2009) studies at doses ≥100–500 mg/kg-day. In the subchronic study, hypertrophy persisted 30 and 90 days after recovery in males, and 30 days after recovery in females (Loveless et al., 2009). In the low confidence (for histopathology outcomes) subchronic study, centrilobular hepatocellular hypertrophy was observed in male rats only (incidence 7/10, 200 mg/kg-day) and resolved after 28-day recovery (Chengelis et al., 2009b). In the chronic study (Klaunig et al., 2015), hepatocellular hypertrophy findings were null consistent with null observations at similar doses in the short-term and subchronic studies.

Table 3-4 Incidence of hepatocellular hypertrophy findings in adult rats due to PFHxA exposure in short-term and subchronic oral toxicity studies

Study design and reference | Dose (mg/kg-d)
Study design and reference | 10 | 20 | 50 | 62.5 | 100 | 125 | 200 | 250 | 500 | 1,000
28-d, female rat (NTP, 2018) | | | | 0/10 | | 0/10 | | 0/10 | 0/10 | 9/10^*^
28-d, male rat (NTP, 2018) | | | | 0/10 | | 0/10 | | 0/10 | 9/10^*^ | 10/10^*^
90-d, female rat; (Chengelis et al., 2009b) | 0/10 | | 0/10 | | | | 0/10
90-d, male rat; (Chengelis et al., 2009b) | 0/10 | | 0/10 | | | | 7/10^*^
90-d, female rat; (Loveless et al., 2009) | | 0/10 | | | 0/10 | | | | 5/10^*^
90-d, male rat; (Loveless et al., 2009) | | 0/10 | | | 4/10^*^ | | | | 10/10^*^
90-d, female rat, 30-d recovery; (Loveless et al., 2009) | | | | | | | | | 4/10^*^
90-d, female rat, 90-d recovery; (Loveless et al., 2009) | | | | | | | | | 0/10
90-d, male rat, 30-d recovery; (Loveless et al., 2009) | | | | | | | | | 9/10^*^
90-d, male rat, 90-d recovery; (Loveless et al., 2009) | | | | | | | | | 6/10^*^

* Indicates instances where statistical significance (p < 0.05) compared to controls was reported by study authors; shaded cells represent doses not included in the individual studies.

Other pathological findings of PFHxA-mediated hepatic effects included increased hepatocellular necrosis in rats, with a significant increase in female rats (n = 99/10 vs. 0/10 in controls, p < 0.05) reported in a short-term study at 1,000 mg/kg-day PFHxA, whereas there were no significant findings of hepatocellular necrosis across male dose groups (NTP, 2018). One subchronic study reported necrosis in male rats (n = 1/10 vs. 0/10 in controls, not statistically significant) (Chengelis et al., 2009b) whereas necrosis was not observed in the other subchronic study (Loveless et al., 2009). In the high confidence chronic study, Klaunig et al. (2015) reported hepatocellular necrosis (n = 12/70 vs. 2/60 in controls, p < 0.05 in the 200 mg/kg-day female dose group (the highest dose tested). The authors noted most necrosis findings were in animals that died or were euthanized prior to scheduled necropsy and the increased mortality was not treatment related, but was due to mechanical injury, gavage trauma, reflux injury, or spontaneous disease processes (Klaunig et al., 2015). The authors reported no treatment-related increases in hepatocellular necrosis (n = 6/70 vs. 4/60 in controls) or necrosis in the centrilobular regions of the liver lobule (n = 1/70 vs. 2/60 in controls) in male rats up to the highest dose for that sex, 100 mg/kg-day. Other findings included nonsignificant congestion in males (n = 23/70 vs. 15/60 in controls) and females (n = 8/70 vs. 6/60 in controls) (Klaunig et al., 2015). Incidence of necrosis were not observed in the short-term study (NTP, 2018), and the subchronic study by Loveless et al. (2009) did not report histological findings other than hepatocellular hypertrophy (no data on necrosis were available).

Other histopathological findings included observations of hepatocellular cytoplasmic alterations (p < 0.05) in adult male and female rats at the highest dose [1,000 mg/kg-day in the short-term study (NTP, 2018)]. All results reported above can be viewed using the HAWC link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-histopathology/).

##### Clinical Chemistry

A clinical chemistry panel measures the proteins, enzymes, chemicals, and waste products in the blood. These measures, when evaluated together and with other biomarkers are informative diagnostic tests of organ function and when interpreted together with histopathology are useful for the assessment of adverse liver effects.

###### Serum Enzymes

Alanine aminotransferase (ALT) and aspartate aminotransferase (AST) are often useful indicators of hepatic enzyme induction or hepatocellular damage as increased serum levels are thought to be due to hepatocyte damage resulting in release into the blood, whereas ALP is localized to the bile canalicular membrane and more indicative of hepatobiliary damage (Hall et al., 2012; Amacher et al., 1998). PFHxA effects on the serum enzymes ALT, AST, and ALP included <2-fold increases in serum enzyme across the three short-term and subchronic studies, except for one 2.4-fold increase in male rats at 200 mg/kg-day in the high confidence subchronic study (Chengelis et al., 2009b). No clear pattern of effects on the serum enzymes were reported in the chronic study (Klaunig et al., 2015), but the highest dose was 100 or 200 mg/kg-day PFHxA in male or female rats, respectively. Full study details are available in Figure 3-3 and by clicking the HAWC link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-hepatc-effects-serum-bioma/). Percent changes in treated relative to controls are provided in Table 3-5, Table 3-6, and Table 3-7.

Specifically, in the short-term study, ALT, AST, and ALP were increased in a dose-response gradient in adult male rats at doses as low as 500 mg/kg-day (NTP, 2018). In female rats, ALT and AST measures were increased in a dose-response gradient at doses as low as 500 mg/kg-day, whereas ALP was increased only in the highest (1,000 mg/kg-day) dose group (NTP, 2018).

ALT increases were observed only in male rats at PFHxA sodium salt exposures as low as 20 mg/kg-day in one subchronic study (Loveless et al., 2009) and in the highest PFHxA dose group (200 mg/kg-day) in the other subchronic study (Chengelis et al., 2009b). AST was increased in only one subchronic study in males at ≥20 mg/kg-day (Loveless et al., 2009). Chengelis et al. (2009b) reported increased AST in males only in the 200 mg/kg-day dose group that resolved after the 30-day recovery (see Table 3-6).

ALP was increased in both subchronic studies with significant increases observed in the highest exposure groups [200 (Loveless et al., 2009) and 500 mg/kg-day (Chengelis et al., 2009b)] that resolved by the 30-day recovery (see Table 3-7). The chronic study did not include a 13-week endpoint that would have been useful for group mean comparisons with the test measures in the subchronic studies (as clinical pathology test values often change with animal age) (AACC, 1992).

Figure 3-3 Clinical chemistry findings (serum enzymes) after short-term, subchronic, and chronic PFHxA exposures (full details available by clicking the HAWC link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-hepatc-effects-serum-bioma/))

Low-resolution chart of clinical chemistry findings (text is blurred).

Table 3-5 Percent change in alanine aminotransferase due to PFHxA exposure in short-term, subchronic, and chronic oral toxicity studies

Study design and reference | Dose (mg/kg-d)
Study design and reference | 2.5 | 5 | 10 | 15 | 20 | 30 | 50 | 62.5 | 100 | 125 | 200 | 250 | 500 | 1,000
28-d, female rat; (NTP, 2018) | | | | | | | | 11 | | 15 | | 10 | 35^*^ | 44^*^
28-d, male rat (NTP, 2018) | | | | | | | | 4 | | 4 | | 8 | 26^*^ | 64^*^
90-d, female rat; (Chengelis et al., 2009b) | | | 60 | | | | 29 | | | | 3
90-d, male rat; (Chengelis et al., 2009b) | | | 12 | | | | 22 | | | | 237^*^
90-d, female rat; (Loveless et al., 2009) | | | | | −46 | | | | −25 | | | | −4
90-d, male rat; (Loveless et al., 2009) | | | | | 33^*^ | | | | 44^*^ | | | | 56^*^
Wk 26, female rat; (Klaunig et al., 2015) | | 44 | | | | −62 | | | | | −57
Wk 26, male rat; (Klaunig et al., 2015) | 10 | | | 12 | | | | | 117
Wk 52, female rat; (Klaunig et al., 2015) | | 7 | | | | −15 | | | | | −10
Wk 52, male rat; (Klaunig et al., 2015) | 194 | | | 2 | | | | | 27

* Indicates instances where statistical significance (p < 0.05) compared to controls was reported by study authors; shaded cells represent doses not included in the individual studies.

Table 3-6 Percent change in aspartate aminotransferase due to PFHxA exposure in short-term, subchronic, and chronic oral toxicity studies

Study design and reference | Dose (mg/kg-d)
Study design and reference | 2.5 | 5 | 10 | 15 | 20 | 30 | 50 | 62.5 | 100 | 125 | 200 | 250 | 500 | 1,000
28-d, female rat; (NTP, 2018) | | | | | | | | −1 | | 0 | | 0 | 11^*^ | 18^*^
28-d, male rat; (NTP, 2018) | | | | | | | | 3 | | 1 | | 6 | 16^*^ | 36^*^
90-d, female rat (Chengelis et al., 2009b) | | | 38 | | | | 18 | | | | 5
90-d, male rat; (Chengelis et al., 2009b) | | | −3 | | | | 16 | | | | 9^*^
90-d, female rat; (Loveless et al., 2009) | | | | | −58 | | | | −44 | | | | −36
90-d, male rat; (Loveless et al., 2009) | | | | | 74 | | | | 25^*^ | | | | 39^*^
Wk 26, female rat (Klaunig et al., 2015) | | −10 | | | | −64 | | | | | −65
Wk 26, male rat; (Klaunig et al., 2015) | −4 | | | −2 | | | | | −63
Wk 52, female rat (Klaunig et al., 2015) | | 11 | | | | −11 | | | | | −15
Wk 52, male rat; (Klaunig et al., 2015) | 32 | | | −1 | | | | | 13

* Indicates instances where statistical significance (p < 0.05) compared to controls was reported by study authors; shaded cells represent doses not included in the individual studies.

Table 3-7 Percent change in alkaline phosphatase due to PFHxA exposure in short-term, subchronic, and chronic oral toxicity studies

Study design and reference | Dose (mg/kg-d)
Study design and reference | 2.5 | 5 | 10 | 15 | 20 | 30 | 50 | 62.5 | 100 | 125 | 200 | 250 | 500 | 1,000
28-d, female rat; (NTP, 2018) | | | | | | | | 8 | | 19 | | 2 | 7 | 38^*^
28-d, male rat; (NTP, 2018) | | | | | | | | −4 | | −2 | | 2 | 22^*^ | 51^*^
90-d, female rat; (Chengelis et al., 2009b) | | | −5 | | | | −22 | | | | 4
90-d, male rat (Chengelis et al., 2009b) | | | −2 | | | | 15 | | | | 34^*^
90-d, female rat; (Loveless et al., 2009) | | | | | −16 | | | | 24 | | | | −18
90-d, male rat (Loveless et al., 2009) | | | | | 17 | | | | 20 | | | | 60^*^
Wk 26, female rat; (Klaunig et al., 2015) | | 16 | | | | 27 | | | | | 7
Wk 26, male rat (Klaunig et al., 2015) | −4 | | | 1 | | | | | −1
Wk 52, female rat; (Klaunig et al., 2015) | | −18 | | | | 4 | | | | | −12
Wk 52, male rat (Klaunig et al., 2015) | −15 | | | −5 | | | | | −2

* Indicates instances where statistical significance (p < 0.05) compared to controls was reported by study authors; shaded cells represent doses not included in the individual studies.

###### Blood Proteins

The two major classes of proteins in the blood stream, albumin, and globulin, are made by the liver (with some globulins also made by the immune system) (Boron and Boulpaep, 2017). Blood proteins are routinely measured in diagnostic panels because changes in blood protein levels, particularly a decrease, can be indicators of protein loss due to kidney disease or impeded production in the liver, such as in liver disease (Boron and Boulpaep, 2017). Blood protein measures (total protein and globulin) were, in general, decreased across short-term (NTP, 2018), and subchronic (Chengelis et al., 2009b; Loveless et al., 2009) studies, with consistent and coherent dose-dependent findings across study designs. No PFHxA-related treatment effects on blood proteins were found in the chronic study at doses up to 100 or 200 mg/kg-day PFHxA (the highest doses administered) in male or female rats, respectively. The pattern of findings suggests a primary effect on blood globulins (decreased) in response to PFHxA exposure that was driving decreases in total protein and increases in the albumin:globulin ratio (A:G). These findings are discussed below and detailed information can be viewed in Figure 3-4 or by clicking on the HAWC link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-hepatic-effects-serum-prot/).

Figure 3-4 Blood protein findings after short-term, subchronic, and chronic PFHxA exposures (full details available by clicking the HAWC link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-hepatic-effects-serum-prot/))

Low-resolution chart of blood protein findings after PFHxA exposure (text is blurred).

Effects on total protein (TP; see Table 3-8)—the total amount of albumin and globulin found in blood, is associated with chronic liver disease (Whalan, 2015)—was decreased up to 20% in male rats receiving a dose ≥125 mg/kg-day in the 28-day study (with a significant trend) (NTP, 2018). A dose-responsive decrease (6%–14%, ≥100 mg/kg-day) in TP also was observed in male rats (Chengelis et al., 2009b; Loveless et al., 2009) with decreased levels observed in males (−6%, 200 mg/kg-day) at the 30-day recovery (Chengelis et al., 2009b). Albumin is a major blood protein that binds fatty acids, cations, bilirubin, thyroxine (T4), and other compounds. Decreased albumin levels are associated with decreased synthesis in the liver, increased catabolism, severe diffuse liver disease, subacute hepatitis, hepatocellular damage, ascites, cirrhosis, and chronic alcoholism (Whalan, 2015). Slight decreases (p < 0.05) in albumin were reported only in males exposed for 28 days to 125 mg/kg-day (6% decrease) and 1,000 mg/kg-day (7% decrease) PFHxA (NTP, 2018). The biological significance of this magnitude of change is unclear. No effects on albumin were identified in the subchronic or chronic studies.

Globulin, a collection of blood proteins larger than albumin made by both the liver and immune system, were decreased in all but the chronic study (see Table 3-9). Globulin decreases were observed in both male and female rats treated with PFHxA in the short-term study at ≥125 mg/kg-day and 1,000 mg/kg-day, respectively (NTP, 2018). Consistent with the short-term study, decreases were also observed in both males and females in the highest dose groups [200 (Chengelis et al., 2009b) and 100 mg/kg-day (Loveless et al., 2009)]. Notably, globulin decreases (10%) persisted at the 30-day recovery in males (200 mg/kg-day) and returned to normal in females (Chengelis et al., 2009b).

The decrease in globulin was consistent with increases in A:G, a routine blood test used to screen for liver, kidney, immune, and gastrointestinal function. The A:G was increased in males and females (113%–160% at ≥250 mg/kg-day and 142% at 1,000 mg/kg-day) with significant trends in both sexes (NTP, 2018). Chengelis et al. (2009b) observed an increase (10%) at the 30-day recovery in rats receiving an oral dose of 200 mg/kg-day.

Table 3-8 Percent change in total protein due to PFHxA exposure in short-term, subchronic, and chronic oral toxicity studies

Study design and reference | Dose (mg/kg-d)
Study design and reference | 2.5 | 5 | 10 | 15 | 20 | 30 | 50 | 62.5 | 100 | 125 | 200 | 250 | 500 | 1,000
28-d, female rat; (NTP, 2018) | | | | | | | | 0 | | 1 | | −1 | −1 | −7^*^
28-d, male rat; (NTP, 2018) | | | | | | | | −4 | | −7^*^ | | −7^*^ | −10^*^ | −20^*^
90-d, female rat; (Chengelis et al., 2009b) | | | 4 | | | | 3 | | | | −4
90-d, male rat (Chengelis et al., 2009b) | | | −3 | | | | −4 | | | | −6^*^
90-d, female rat; 30-d recovery; (Chengelis et al., 2009b) | | | | | | | | | | | −3
90-d, male rat; 30-d recovery; (Chengelis et al., 2009b) | | | | | | | | | | | −6^*^
90-d, female rat; (Loveless et al., 2009) | | | | | −1 | | | | −1 | | | | −3
90-d, male rat (Loveless et al., 2009) | | | | | 0 | | | | −6^*^ | | | | −14^*^
2-yr, female rat (Klaunig et al., 2015) | | −1 | | | | 1 | | | | | 0
2-yr, male rat; (Klaunig et al., 2015) | −1 | | | 0 | | | | | −3

* Indicates instances where statistical significance (p < 0.05) compared to controls was reported by study authors; shaded cells represent doses not included in the individual studies.

Table 3-9 Percent change in globulins due to PFHxA exposure in short term, subchronic, and chronic oral toxicity studies

Study design and reference | Dose (mg/kg-d)
Study design and reference | 2.5 | 5 | 10 | 15 | 20 | 30 | 50 | 62.5 | 100 | 125 | 200 | 250 | 500 | 1,000
28-d, female rat; (NTP, 2018) | | | | | | | | −6 | | −4 | | −9 | −7^*^ | −28^*^
28-d, male rat; (NTP, 2018) | | | | | | | | −7 | | −9 | | −14^*^ | −24^*^ | −40^*^
90-d, female rat; (Chengelis et al., 2009b) | | | 0 | | | | 0 | | | | −15^*^
90-d, male rat (Chengelis et al., 2009b) | | | −7 | | | | −11^*^ | | | | −11^*^
90-d, female rat; 30-d recovery; (Chengelis et al., 2009b) | | | | | | | | | | | 0
90-d, male rat; 30-d recovery; (Chengelis et al., 2009b) | | | | | | | | | | | −10^*^
90-d, female rat (Loveless et al., 2009) | | | | | 0 | | | | −3 | | | | −11^*^
90-d, male rat (Loveless et al., 2009) | | | | | 0 | | | | −13^*^ | | | | −28^*^
2-yr, female rat; (Klaunig et al., 2015) | | −4 | | | | 4 | | | | | −4^*^
2-yr, male rat; (Klaunig et al., 2015) | −4 | | | 4 | | | | | −4

* Indicates instances where statistical significance (p < 0.05) compared to controls was reported by study authors; shaded cells represent doses not included in the individual studies.

##### Hepatobiliary Components

Other indicators of potential liver dysfunction or injury included impacts on bile components essential for normal lipid metabolism and red blood cell breakdown. ALP (discussed with serum enzymes and in Table 3-7, see above) is an indicator of bile duct obstruction and was consistently increased in male and female rats in the short-term study (NTP, 2018) and subchronic studies (Chengelis et al., 2009b; Loveless et al., 2009). In the short-term study (NTP, 2018), bile acids were increased at the highest dose (1,000 mg/kg-day) with a significant trend (a possible indication of cholestatic liver injury), and bilirubin was decreased in a dose-response gradient across both the short-term and subchronic (Loveless et al., 2009) studies (see Figure 3-5). Lower than normal bilirubin levels are usually not a concern and can be reduced in response to increased conjugation rates after hepatic enzyme induction and excretion into bile (Hall et al., 2012).

Figure 3-5 Hepatobiliary findings in rats exposed by gavage to PFHxA or PFHxA sodium salt (full details available by clicking the HAWC link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-hepatic-effects-hepatobili/))

Chart of hepatobiliary findings in rats.

#### Mechanistic Evidence and Supplemental Information

The available evidence base reports increased liver weight, hepatocellular hypertrophy, hepatocellular necrosis, increased (1.5–2.5-fold) serum enzymes, increased peroxisomal beta oxidation, decreased total protein (driven by decreased globulin), and decreased bilirubin levels in rats exposed to PFHxA. This collection of findings was considered for their potential adversity and relevance in humans using Hall criteria (Hall et al., 2012) along with other available supplemental mechanistic evidence. The mechanistic findings (i.e., -omics data, transactivation assays, oxidative stress assays, knockout mouse models) were coherent with animal findings of PFHxA mediated liver injury. The supplemental mechanistic evidence from other short-chain PFAS (e.g., PFBA) supported both PPARα independent and dependent pathways that are relevant in humans, increasing the plausibility that these PFAS-mediated responses also apply to PFHxA. Additional evidence from non-mammalian models is available and summarized in the PFHxA Literature Tagtree (https://hawc.epa.gov/lit/assessment/100500070/references/visualization/).

##### Considerations for Potentially Adaptive Versus Adverse Responses

Considering that the hepatic effects of PFHxA exposure (increased liver weight and hepatocyte hypertrophy) observed in rodents could represent adaptive responses, the potential adversity of these effects was a key consideration and analyzed. In the absence of a known mechanism leading to increased liver weight, hepatocellular hypertrophy, and necrosis, the evidence on PFHxA-mediated hepatotoxicity was evaluated to inform interpretations regarding adversity utilizing guidance from Hall et al. (2012). Increased liver weight and hepatocellular hypertrophy can be associated with changes that are adaptive in nature (Hall et al., 2012) and not necessarily indicative of adverse effects unless observed in concordance with other clinical, pathological markers of overt liver toxicity (see Appendix A). The IRIS PFAS Assessment Protocol (which applies to PFHxA) states the panel recommendations from Hall et al. (2012) can be used to judge whether observed hepatic effects are adverse or adaptive in nature. Given that Hall et al. (2012) was focused on framing noncancer liver effects in the context of progression to liver tumors, however, the protocol further indicates that “…consultation of additional relevant information will be considered to interpret the adversity of noncancer liver effects over a lifetime exposure, taking into account that effects perceived as adaptive can progress into more severe responses and lead to cell injury.” Hall et al. (2012) indicates that additional evidence must be considered when determining adverse versus adaptive response in rodents in the context of hepatocellular hypertrophy that include:

1) Is there histological evidence of the following structural degenerative or necrotic changes?
  - Hepatocyte necrosis, fibrosis, inflammation, and steatotic vacuolar degeneration
  - Biliary/oval cell proliferation, degeneration, fibrosis, and cholestasis
  - Necrosis and degeneration of other resident cells within the liver
2) In the absence of histological changes, using a weight-of-evidence approach, is there clinical pathology evidence of hepatocyte damage characterized by a dose dependent and biologically significant and consistent increase in at least two of the following liver parameters?
  - At least ×2 to ×3 increase in ALT
  - A biologically significant change in other biomarkers of hepatobiliary change (ALP, AST, γGT, GLDH, etc.)
  - A biologically significant change in another clinical pathology marker indicating liver dysfunction (albumin, bilirubin, bile acids, coagulation factors, cholesterol, triglycerides, etc.)

With regard to Step 1 above, histological evidence of structural change included necrosis in females rats only (incidence of 12/70) receiving 200 mg/kg-day in the chronic study (note the highest dose in male rats was half the female dose, 100 mg/kg-d)(Klaunig et al., 2015) and 2.5-5 times lower than the highest dose in the short term (NTP, 2018) or the subchronic studies (Chengelis et al., 2009b; Loveless et al., 2009). There was one incidence of necrosis male rats only (n = 1/10 vs. 0/10 in controls, not significant) from the short-term study (NTP, 2018), and no findings of necrosis from either subchronic study (Chengelis et al., 2009b; Loveless et al., 2009). Histological findings did include increased incidence of hepatocellular hypertrophy from the short term and both subchronic studies. Notably, hypertrophy findings persisted in both male and female rats 90-day after recovery (Loveless et al., 2009). Although some uncertainties remain, the necrosis observed in the female rats in the chronic study (and at a highest dose in a short-term study) support the adversity of the hepatic effects of PFHxA regarding Step 1.

Regarding Step 2 above, other liver parameter effects were observed after PFHxA exposure and included increased peroxisomal beta oxidation in both subchronic studies (Chengelis et al., 2009b; Loveless et al., 2009) that persisted at 30 days recovery in both male and female rats (Loveless et al., 2009). The serum enzymes ALT was increased 2-3-fold in the short term and subchronic studies. AST and ALP were also significantly increased, although the magnitude of the response was <2-fold, at the same or lower doses than the observed increases in hepatocellular hypertrophy. Other parameters characterized by a dose-dependent PFHxA-mediated effect included decreased globulin, decreased total protein, and decreased bilirubin. While the collection of findings was generally observed across both sexes, the magnitude of the change was greater in males than females. This sex-specific difference is possibly explained by the increased clearance rate in females compared with males. Although some uncertainties remain, the observed liver parameter changes in the female and male rats in the subchronic studies (e.g., increased liver enzymes, increased peroxisomal beta oxidation, decreased blood proteins) support the adversity of the hepatic effects of PFHxA regarding Step 1.

Considering the Hall et al. (2012) criteria above, the observed increase in relative liver weight and hepatocellular hypertrophy in rats exposed to PFHxA are interpreted as adverse, human relevant, and potentially leading to increasingly severe outcomes such as necrosis.

##### Peroxisomal Beta Oxidation

Peroxisomal proliferation can be induced within the peroxisomes to perform beta oxidation of lipids into acetyl CoA and hydrogen peroxide (H_2_O_2_) (Reddy, 2004). Hydrogen peroxide is a reactive metabolite and can cause oxidative damage to the surrounding tissue. Two subchronic studies measured PFHxA induction of peroxisomal beta oxidation activity in male and female rats (Chengelis et al., 2009b; Loveless et al., 2009) (see Figure 3-6) and both were considered medium or high confidence for this outcome. Chengelis et al. (2009b) reported an increase (p < 0.05, 1.37-fold) in males treated with 200 mg/kg-day at 13 weeks. Loveless et al. (2009) found increased peroxisomal beta oxidation activity in both sexes gavaged with 500 mg/kg-day for 10 and 90 days (males, 3.1- and 4.36-fold, respectively; females, 1.45- and 2.67-fold, respectively). Notably, increased activity persisted after the 30-day recovery and male rats were more sensitive than females, with males in the 100 mg/kg-day group also showing increased peroxisomal beta oxidation (Loveless et al., 2009).

Figure 3-6 Peroxisomal beta oxidation activity in rats exposed by gavage to PFHxA or PFHxA sodium salt (full details available by clicking the HAWC link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-hepatic-effects-peroxisome/))

Chart displaying peroxisomal beta oxidation activity in rats.

##### Considerations Related to Human Relevance

Peroxisomal beta oxidation in rodents is mediated primarily by PPARα. The induction of both PPARα and CAR target gene expression were observed after PFHxA exposure in both the short-term and subchronic rodent studies (NTP, 2018; Chengelis et al., 2009b; Loveless et al., 2009). Specifically, in the short-term study, NTP (2018), in vivo PFHxA exposure in rats elicited significant dose-related increases in the liver expression of the PPARα target genes acyl-CoA oxidase (Acox1, up to 2-fold increase) and cytochrome P450 4a1 (Cyp4a1, up to 12.5-fold increase). In the same short-term study, constitutive androstane receptor (CAR) target genes cytochrome P450 2b1 (Cyp2b1, up to 7-fold increase) and cytochrome P450 2b2 (Cyp2b2, up to 3-fold increase) were also induced after PFHxA exposure. Functional evidence of PPARα activation by PFHxA exposure was provided by the NTP (2018) short-term study where increases (up to 16-fold) in Acyl-CoA oxidase activity in male rats receiving >250 mg/kg-day PFHxA (not measured in females) were observed.

The hepatic effects of PFHxA exposure observed in the rat studies discussed above were also evaluated in pathogen-free ICR mice receiving 0, 50, or 200 mg/kg PFHxA by oral gavage daily for 60 days (Jiang et al., 2021). The observed hepatotoxicity in ICR mice was similar to the SD rats and included histopathological findings of hepatocellular hypertrophy, inflammatory cell infiltration, and degeneration. These findings were coherent with results from whole liver RNA-seq and proteomics analysis that identified pathways enriched with differentially regulated genes and proteins involved in PPAR signaling pathways (Jiang et al., 2021).

The available evidence also included evidence for mechanistic information supporting biologically plausible pathways (including those mediated by PPARα activation) leading to the observed PFHxA-mediated hepatoxicity in rodents and considered relevant in humans. For example, PFHxA activation of both rodent and human PPARα in HepG2 cells at concentrations between 1–30 μM; 12.2 μM PFHxA Buhrke et al. (2013). The activation of human PPARα by short and long chain PFAS was also observed by Behr et al. (2020) in human HepG2 cells. In another study, Wolf et al. (2008) examined, PPARα activation by PFHxA in COS1 cells transfected with reporter gene constructs containing either the mouse or human PPARα ligand binding domain fused to a Gal4 DNA binding domain under control of an SV-40 promoter in a luciferase reporter plasmid. These assays indicated that both mouse and human PPARα are activated by PFHxA in a treatment-related manner with PFHxA being a more potent activator of the human (lowest-observed-effect concentration, LOEC = 10 μM) compared to the mouse (LOEC = 20 μM) receptor (Wolf et al., 2008). While the transactivation studies of Wolf et al. (2008) indicated PFHxA activation of both the mouse and human PPARα, significant effects were reported only for treated vs. control within a species. In sharp contrast to all other studies Buhrke et al. (2013), Wolf et al. (2008), Wolf et al. (2008), and Jiang et al. (2021), Bjork and Wallace (2009) reported PFAS activation of PPARα target gene expression in rat, but not human immortalized and primary hepatocytes exposed. However, the outcome was considered low confidence due to notable concern that variables were unaccounted or uncontrolled for (i.e., no positive control, no baseline characterization of gene expression changes or PPAR activity).

Additional in vitro evidence for PFHxA effects in human cell lines (including HepG2 and HepaRG cells) is available from EPA’s CompTox Chemicals Dashboard (https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID3031862#bioactivity) (U.S. EPA, 2018a). Transactivation assays in immortalized human HepG2 cells indicated PFHxA treatment effects that included activation of the transcription factors PPARα and hypoxia inducible factor 1 subunit alpha (HIF1α, a transcriptional regulator of genes involved in the hypoxia response). Similarly, gene expression assays in human-derived HepaRG cells identified the induction of 16 genes including several cytochrome P450 family members, transporters, kinases, and oxidase/oxidoreductase related activities that are primarily involved in oxidation/reduction and/or lipid metabolism (see Table 3-10), consistent with evidence of short and long chain PFAS (including PFHxA) activation of both human and rodent PPAR-dependent and independent pathways. Altogether, the mostly consistent activation across species of PPARα by PFHxA provides further support for the human relevance of the PFHxA-induced liver changes observed in rodents.

Table 3-10 Gene targets identified from EPA CompTox Chemicals Dashboard (https://www.epa.gov/chemical-research/comptox-chemicals-dashboard) after PFHxA treatment in human liver cell lines^a^

Gene Symbol | Gene Name | AC50^b^ | LOGAC50 | BMAD^c^
ABCG2 (https://www.ncbi.nlm.nih.gov/gene/9429) * | ATP-binding cassette, sub-family G (WHITE), member 2 (Junior blood group) (https://www.ncbi.nlm.nih.gov/gene/9429) | 9.49 | 0.977 | 0.201
ACOX1 (https://www.ncbi.nlm.nih.gov/gene/51) * | acyl-CoA oxidase 1, palmitoyl (https://www.ncbi.nlm.nih.gov/gene/51) | 9.47 | 0.976 | 0.135
ADK (https://www.ncbi.nlm.nih.gov/gene/132) | adenosine kinase (https://www.ncbi.nlm.nih.gov/gene/132) | 2.88 | 0.459 | 0.166
CYP2B6 (https://www.ncbi.nlm.nih.gov/gene/1555) * | cytochrome P450, family 2, subfamily B, polypeptide 6 (https://www.ncbi.nlm.nih.gov/gene/1555) | 19.1 | 1.28 | 0.251
CYP2C19 (https://www.ncbi.nlm.nih.gov/gene/1557) | cytochrome P450, family 2, subfamily C, polypeptide 19 (https://www.ncbi.nlm.nih.gov/gene/1557) | 5.21 | 0.717 | 0.187
CYP2C8 (https://www.ncbi.nlm.nih.gov/gene/1558) * | cytochrome P450, family 2, subfamily C, polypeptide 8 (https://www.ncbi.nlm.nih.gov/gene/1558) | 7.88 | 0.896 | 0.216
CYP2C9 (https://www.ncbi.nlm.nih.gov/gene/1559) | cytochrome P450, family 2, subfamily C, polypeptide 9 (https://www.ncbi.nlm.nih.gov/gene/1559) | 6.53 | 0.815 | 0.314
CYP3A7 (https://www.ncbi.nlm.nih.gov/gene/1551) | cytochrome P450, family 3, subfamily A, polypeptide 7 (https://www.ncbi.nlm.nih.gov/gene/1551) | 10.3 | 1.01 | 0.259
CYP4A11 (https://www.ncbi.nlm.nih.gov/gene/1579) | cytochrome P450, family 4, subfamily A, polypeptide 11 (https://www.ncbi.nlm.nih.gov/gene/1579) | 45.3 | 1.66 | 0.213
CYP4A22 (https://www.ncbi.nlm.nih.gov/gene/284541) | cytochrome P450, family 4, subfamily A, polypeptide 22 (https://www.ncbi.nlm.nih.gov/gene/284541) | 57.6 | 1.76 | 0.269
FABP1 (https://www.ncbi.nlm.nih.gov/gene/2168) * | fatty acid binding protein 1, liver (https://www.ncbi.nlm.nih.gov/gene/2168) | 22.3 | 1.35 | 0.161
FMO3 (https://www.ncbi.nlm.nih.gov/gene/2328) | flavin containing monooxygenase 3 (https://www.ncbi.nlm.nih.gov/gene/2328) | 13.3 | 1.12 | 0.145
HMGCS2 (https://www.ncbi.nlm.nih.gov/gene/3158) * | 3-hydroxy-3-methylglutaryl-CoA synthase 2 (mitochondrial) (https://www.ncbi.nlm.nih.gov/gene/3158) | 4.13 | 0.616 | 0.175
PDK4 (https://www.ncbi.nlm.nih.gov/gene/5166) * | pyruvate dehydrogenase kinase, isozyme 4 (https://www.ncbi.nlm.nih.gov/gene/5166) | 20.9 | 1.32 | 0.161
SLCO1B1 (https://www.ncbi.nlm.nih.gov/gene/10599) | solute carrier organic anion transporter family, member 1B1 (https://www.ncbi.nlm.nih.gov/gene/10599) | 9.82 | 0.992 | 0.181
UGT1A1 (https://www.ncbi.nlm.nih.gov/gene/54658) | UDP glucuronosyltransferase 1 family, polypeptide A1 (https://www.ncbi.nlm.nih.gov/gene/54658) | 15.1 | 1.18 | 0.221

* PPARα target gene (http://www.ppargene.org/index.php).

a After filtering out results flagged in the Dashboard as uncertain (e.g., high degree of variability) or occurring at high concentrations associated with cytotoxicity (U.S. EPA, 2018c; Filer et al., 2016; Filer, 2015), 19 assay targets remained from human liver cell-based assays (at up to 200 µM PFHxA).

b AC50 – active concentration (µM) that elicited half maximal response.

c BMAD – baseline median absolute deviation.

The data discussed above suggest similar PPARα activation occurs in both rodents and humans (at least in vitro). Potential pathways such as PPARα and CAR activation can contribute to some of the hepatic changes caused by PFHxA exposure, including hypertrophy. Studies of the prototypical PPARα agonist, WY-14643, indicate an increased sensitivity of rodents as compared to humans; however, the PFHxA-specific data do not demonstrate such clear differences with this structurally different compound.

Overall, although the PFHxA-specific data informing possible biological pathways leading to the observed hepatic effects are sparse and uncertainties remain, collectively the available in vivo and in vitro evidence for PFHxA support the potential for the responses observed in rodents to be relevant to humans.

##### Evidence from Other PFAS

Although no direct in vivo evidence is available for PFHxA effects in PPARα null rodent models, evidence from other PFAS, as well as PFAS exposures in PPARα null and humanized mouse models provide evidence that PPARα independent and dependent pathways from other PFAS are consistent for other short-chain PFAS (e.g., PFBA) (U.S. EPA, 2022b), and possibly long-chain PFAS as well (e.g., PFNA, PFOA, PFOS) (U.S. EPA, 2023a, b), supporting the plausibility that these PFAS-mediated responses also apply to PFHxA. Specifically. Specifically, Foreman et al. (2009) also observed increased liver weight, hepatic lipid accumulation, ALT increases >2-fold, and pathologically similar (severity and incidence) hepatocellular hypertrophy in male SV129 wild-type SV and humanized PPARα mice exposed to PFBA. Although there is no evidence specifically challenging the role of PPARα in PFHxA-mediated hepatotoxicity, based on PFHxA structural similarity with other PFAS, most notably PFBA, it is reasonable to infer that PFHxA exposure in genetic mouse model systems would elicit similar effects.

#### Evidence Integration

The human evidence base is limited to a single medium confidence study reporting null associations between serum biomarker levels and PFHxA exposure. Based on these data, there is indeterminate human evidence of hepatic effects.

The hepatic findings in rodents exposed to PFHxA included increased relative liver weight observed with increased hepatocellular hypertrophy at doses as low as 100 mg/kg-day (Loveless et al., 2009) and 200 mg/kg-day (Chengelis et al., 2009b) in male rats that persisted after 30- and 90-day recovery. Corroborative evidence for adverse hepatotoxicity included increased serum enzymes, (e.g., ALT increased >2-fold) in the subchronic studies, although a dose-responsive relationship was observed in the short term, but not the subchronic, studies. Serum enzyme changes were not observed in the chronic study (Klaunig et al., 2015). Hepatocellular necrosis was observed in male rats in a high confidence short term study (NTP, 2018) at 1,000 mg/kg-day, low confidence subchronic study (Chengelis et al., 2009b) and in the high confidence chronic study (female rats) (Klaunig et al., 2015) at 200 mg/kg-day. Other clinical findings altered by PFHxA exposure included decreased bilirubin and decreased total protein mainly driven by decreases in globulins (see Clinical Chemistry section above). These findings (i.e., increased liver weight with concurrent hepatocellular hypertrophy, increases in ALT, and decreased protein levels) were considered adverse as they might lead to the necrosis observed in females at 200 mg/kg-day in the chronic study. In general, the pattern of findings suggests a generally increased sensitivity in males as compared to females. Overall, there is robust animal evidence of hepatic effects. This judgment is based on four studies in Sprague-Dawley rats that were generally rated high confidence on the outcome-specific evaluations.

Although multiple biological pathways could lead to the histopathological findings mentioned above, the PFHxA database for molecular evidence was predominantly limited to PPARα pathways and included in vitro assays measuring PFHxA induction of PPARα activity (Wolf et al., 2014; Wolf et al., 2008), peroxisomal beta oxidation activity (NTP, 2018; Chengelis et al., 2009b; Loveless et al., 2009), changes in gene expression for CAR and PPARα cytochrome P450 gene expression (NTP, 2018), and in vivo PPARα knockout and humanized genetic mouse models exposed to PFAS structurally similar to PFHxA (Das et al., 2017; Rosen et al., 2017; Foreman et al., 2009). Wolf et al. (2008) and Wolf et al. (2014) found evidence that PFHxA activated the human PPARα receptor concentrations that in rodent. Dose-responsive increases in peroxisomal beta oxidation activity were observed in two subchronic studies (Chengelis et al., 2009b; Loveless et al., 2009) at a dose as low as 100 mg/kg-day and this effect persisted after the 30-day recovery (Loveless et al., 2009). Evidence for pathways other than PPARα and CAR were available from genetic PPARα knockout mouse studies evaluating the effects of PFAS exposure (Das et al., 2017; Rosen et al., 2017; Foreman et al., 2009) that found similar levels of increased liver weight and incidence of hepatocellular hypertrophy when comparing between PPARα knockout, humanized, and wild-type mouse models, suggesting PPARα dependent and independent pathways are activated by other PFAS, most notably PFBA (U.S. EPA, 2022b), a short-chain PFAS like PFHxA. Further supplemental mechanistic evidence indicated that human PPARα and related gene expression is activated by PFHxA treatment in vitro. Thus, taken together, the findings observed in rodent models are interpreted as relevant to humans.

Overall, the currently available evidence indicates that PFHxA likely causes hepatic effects in humans given sufficient exposure conditions (see Table 3-11).^5^ This conclusion is based on studies of animals showing increased liver weight, hepatocellular hypertrophy, increased serum enzymes (including >2-fold ALT) and decreased serum globulins generally occurring at ≥100 mg/kg-day within the evidence base of four primarily high confidence studies of short-term, subchronic, and chronic PFHxA exposure in (primarily male) rats. The findings in rats were determined to be adverse and relevant to humans, with the likely involvement of both PPARα-dependent and -independent pathways and consistent with hepatic effects identified for other PFAS (U.S. Environmental Protection Agency: (U.S. EPA, 2022b; ATSDR, 2021; U.S. EPA, 2021a, 2018b, 2016a, b)) (summarized in Section 4, see Table 4-1).

Table 3-11 Evidence profile table for hepatic effects

Evidence stream summary and interpretation | | | | | Evidence integration summary judgment
Evidence from studies of exposed humans | | | | | ⊕⊕⊙; Evidence indicates (likely); Primary basis:; Four generally high confidence studies in rats ranging from short-term to chronic exposure, generally in males at ≥100 mg/kgd PFHxA; Human relevance:; Given the induction of human PPARα by PFHxA, as well as support for involvement of both PPARα-dependent and independent pathways for PFHxA and related PFAS, effects in rats are considered relevant to humans; Cross-stream coherence:; N/A (human evidence indeterminate); Susceptible populations and lifestages:; No evidence to inform
Studies and confidence | Factors that increase certainty | Factors that decrease certainty | Summary and key findings | Evidence stream judgment
[underlined: Serum Biomarkers]; 2 low (https://hawcprd.epa.gov/study/100517559/) confidence studies | - No factors noted | - Low confidence studies (low sensitivity) | - No association of PFHxA with serum biomarkers | ⊙⊙⊙; Indeterminate
Evidence from animal studies
Studies and confidence | Factors that increase certainty | Factors that decrease certainty | Summary and key findings | Evidence stream judgment
Organ Weight (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-hepatic-effects-liver-weig/); 3 high (https://hawcprd.epa.gov/summary/visual/100500177/) confidence:; 28-d; 90-d (2 studies) | - Consistent increases, all studies, and sexes; - Dose-response observed in all studies; - Coherence with histopathology; - Large magnitude of effect, up to 63%; - High confidence studies | - No factors noted | - Increased liver weight at ≥200 mg/kg-d; stronger in males | ⊕⊕⊙; Moderate; Findings considered adverse based on observed liver parameter changes in the female and male rats in the subchronic studies (e.g., increased liver enzymes, increased peroxisomal beta oxidation, decreased blood proteins) at similar doses, but lower than doses at which necrosis was observed (200 mg/kg-d) consistent with the progressive change to necrosis support the adversity of the hepatic effects with potential for progression for more severe phenotypes, including necrosis with longer-term exposure.
Histopathology (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-hepatc-effects-serum-bioma/); 3 high (https://hawcprd.epa.gov/summary/visual/100500177/) confidence studies in adult rats:; 28-d; 90-d; 2-yr; 1 low (https://hawcprd.epa.gov/summary/visual/100500177/) confidence study in adult rats:; 90-d | - Consistent cellular hypertrophy across studies and sexes; - Coherence with liver weight; - Dose-response for hypertrophy; - Concerning severity of effect—necrosis (with short term, subchronic, and chronic exposure); - High confidence studies | - No factors noted | - Cellular hypertrophy at ≥100 mg/kg-d; stronger in males; - Necrosis in females at 200 mg/kg-d
Serum Biomarkers of Hepatic Injury (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-hepatc-effects-serum-bioma/); 4 high (https://hawcprd.epa.gov/summary/visual/100500177/) confidence studies in adult rats:; 28-d; 90-d (2 studies); 2-yr | - Consistent increases in ALT, AST, and ALP, and decreases in bilirubin, across studies; - Magnitude of effect, >2-fold ALT; - Dose-response for total protein; - Coherence of ALP and bilirubin; - High confidence studies | - No factors noted | - Increased ALT, AST, ALP, and bile salts/acids at ≥20, ≥100, ≥200, and 500 mg/kg-d, respectively; stronger in males; - Decreased total protein at ≥100 mg/kg-d; stronger in males
Mechanistic evidence and supplemental information
Biological events or pathways | Primary evidence evaluated; Key findings, interpretation, and limitations | | | Evidence stream summary
Molecular Initiating; Events—PPARα | Key findings and interpretation:; - Consistent studies demonstrating In vitro induction of human and rodent PPARα activity in trans-activation experiments. Reporter gene activation at lower effective concentrations in human versus mouse constructs.; - Induction of PPARα in association with hepatic effects in a short-term oral exposure study.; - PFHxA binding to and activation of human PPARα.; - Activation of PPARα target gene expression in rodents.; - Findings coherent with animal findings of increased peroxisomal beta oxidation activity. | | | - Biologically plausible support for PPARα-dependent and independent pathways contributing to hepatic effects of PFHxA that are relevant in humans.
Molecular Initiating; Events—Other Pathways | Key findings and interpretation:; - Indirect evidence supporting activation of PPARα-independent pathways contributing to hepatic effects like those observed for PFHxA in PPARα knockout and humanized mice after short-term oral exposure to PFAS other than PFHxA, including the related PFAS, PFBA.; - -omics evidence supporting differential regulation of genes regulated by PPARα dependent and independent pathways; Limitations: Small evidence base with no experiments specifically challenging the role of PPARα in PFHxA-induced hepatic injury. | | | - Biologically plausible support for PPARα-dependent and independent pathways contributing to hepatic effects of PFHxA that are relevant in humans.
Organ Level Effects | Key findings and interpretation:; - Increased peroxisomal beta oxidation activity that persisted 30 d post-exposure (likely not a transient, adaptive response) in short-term and subchronic rat studies of oral PFHxA exposure.; - Indirect evidence of fatty liver, hepatocellular hypertrophy, and hepatomegaly in PPARα KO mice after short-term oral exposure to PFAS other than PFHxA.; Limitations: Small evidence base and the most compelling in vivo evidence for PPARα-independent pathways with hepatic effects did not specifically test PFHxA. | | | - Biologically plausible support for PPARα-dependent and independent pathways contributing to hepatic effects of PFHxA that are relevant in humans.

### 3.2.2 Developmental Effects

#### Human

A single study evaluated associations between PFHxA and developmental effects, specifically birth size and postnatal growth, in a study in China with follow-up to 5 months after birth (Jin et al., 2020). This study was considered uninformative and not considered further due to lack of consideration of potential confounding, including parity, socioeconomic status and maternal age.

#### Animal

Three studies described in two publications examined developmental outcomes, including offspring viability, body weight, eye opening, and malformations and variations. Rats were exposed to PFHxA sodium salt during gestation (gestation day [GD] 6–20; developmental study) or continuously exposed throughout gestation and lactation (reproductive study) (Loveless et al., 2009). Mice were exposed to PFHxA ammonium salt from GD 6–18 (Iwai and Hoberman, 2014). These studies were rated high confidence. The results from outcome-specific, confidence evaluations for all individual reproductive outcomes are presented in Table 3-12, and details are available by clicking the HAWC link (https://hawcprd.epa.gov/summary/visual/100500177/). Effects on male and female reproductive system development following developmental exposure are discussed in the male and female reproductive effects sections, respectively (see Sections 3.2.6 and 3.2.7).

Table 3-12 Study design characteristics and outcome-specific study confidence for developmental endpoints

Study | Species, strain (sex) | Exposure design | Exposure route and dose | Offspring viability | Offspring body weight | Eye Opening | Malformations and Variations
Loveless et al. (2009) | Rat, Crl:CD(SD) Sprague–Dawley (male and female) | Reproductive study: P_0_ females dosed 70 d prior to cohabitation, through gestation and lactation (126 d); P_0_ males dosed for 110 d; Developmental study: GD 6–20 | Gavage^a^; Female: 0, 20, 100, 500 mg/kg-d | ++ | ++ | ++ | ++
Iwai and Hoberman (2014) ^c^ | Mouse, Crl:CD1(ICR) (male and female) | Developmental: GD 6–18 | Gavage^b^; Phase 1: 0, 100, 350, 500 mg/kg-d; Phase 2: 0, 7, 35, 175 mg/kg-d | ++ | ++ | ++ | NM

++ Outcome rating of high confidence; NM, outcome not measured.

a,b Study evaluation for animal toxicological developmental endpoints reported from studies with rats receiving PFHxA sodium salt^a^ or PFHxA ammonium salt^b^ by gavage. Study evaluation details for all outcomes are available by clicking the HAWC link.

c Phase 1 was a range finding study used to determine the appropriate dose range for identification of a NOAEL in Phase 2.

##### Offspring Mortality

Potential effects of PFHxA exposure on offspring viability were evaluated in a developmental study (Iwai and Hoberman, 2014) and a one-generation reproductive study (Loveless et al., 2009). Mice exposed to PFHxA ammonium salts during gestation (GD 6–18) showed a dose-dependent increase in the incidence of offspring mortalities occurring both pre- and postnatally (Iwai and Hoberman, 2014). Most deaths occurred between postnatal day (PND) 0–7, with a statistically significant increase observed in the 350 and 500 mg/kg-day dose groups on PND 1–4. These effects were observed across two experimental cohorts with different but overlapping dose ranges (cohort 1: 0, 100, 350, and 500 mg/kg-day; cohort 2: 0, 7, 35, and 175 mg/kg-day). Early postnatal losses are reflected in treatment-related effects on several measures of offspring viability for the 500 mg/kg-day dose group. Specifically, statistically significant changes were observed in the following related outcomes: decreased viability index for PND 0–4 and PND 0–7, fewer surviving pups per litter on PND 20, and increased incidence of total litter loss between PND 0–3 (5 of 17 for the 500 mg/kg-day group compared to 1 of 19 dams for concurrent controls). A dose-dependent increase in the number of stillbirths, a measure of prenatal mortality, was also reported across the two phases of the experiment (incidence of 3/241, 5/245, and 19/177 for the 175, 350, and 500 mg/kg-d dose groups, respectively). Results are summarized in Figure 3-7 and Table 3-13.

Figure 3-7 Developmental effects on offspring viability in mice exposed to PFHxA ammonium salt (HAWC: PFHxA – Animal Toxicity Developmental Effects link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-developmental-effects-viab/))

The Iwai and Hoberman (2014) study was conducted in two phases. Phase 1 was a range-finding study (100, 350, or 500 mg/kg-d) used to determine the appropriate doses (7, 35, 175 mg/kg-d) to identify a NOAEL in Phase 2.

Chart of development effects on offspring viability.

Table 3-13 Incidence of perinatal mortality following PFHxA ammonium salt exposure in a developmental oral toxicity study

Study design and reference | Dose (mg/kg-d)
Study design and reference | 0; (Cohort 1) | 0; (Cohort 2) | 7 | 35 | 100 | 175 | 350 | 500
Stillbirths, male and female (combined) mice (Iwai and Hoberman, 2014) | 4 | 0 | 0^a^ | 0 | 0 | 3^*^ | 5^a^ | 19^a,*^
Mortalities, PND 0, male and female (combined) mice (Iwai and Hoberman, 2014) | 0 | 0 | 0 | 0 | 0 | 4 | 3^a^ | 21^a,*^
Mortalities, PNDs 1–4, male and female (combined) mice (Iwai and Hoberman, 2014) | 2 | 1^a^ | 3^a^ | 2 | 2^a^ | 0^a^ | 13^a,*^ | 15^a,*^
Mortalities, PNDs 5–7, male and female (combined) mice (Iwai and Hoberman, 2014) | 0^a^ | 1 | 0^a^ | 0 | 0^b^ | 3^a^ | 2^a^ | 0^a^
Mortalities, PNDs 8–14, male and female (combined) mice (Iwai and Hoberman, 2014) | 0 | 0 | 0 | 0 | 0^a,b^ | 0^a^ | 0^a^ | 0^a^
Mortalities, PNDs 15–20, male and female (combined) mice (Iwai and Hoberman, 2014) | 0 | 0 | 0 | 0 | 2^b^ | 1 | 0 | 0
Total pups delivered, male and female (combined) mice (Iwai and Hoberman, 2014) | 221 | 249 | 211 | 232 | 250 | 241 | 245 | 177
Cumulative perinatal mortality/total pups delivered, male and female (combined) mice (Iwai and Hoberman, 2014) | 6/221 | 2/249 | 3/211 | 2/232 | 4/250 | 11/241 | 23/245 | 55/177

The Iwai and Hoberman (2014) study was conducted in two phases. Phase 1 was a range-finding study (100, 350, or 500 mg/kg-d) used to determine the appropriate doses (7, 35, 175 mg/kg-d) to identify a NOAEL in Phase 2.

* Indicates instances where statistical significance (p < 0.05) compared to controls was reported by study authors.

a Excludes animals that were missing and presumed cannibalized or where vital status at birth was uncertain due to maternal cannibalization or autolysis.

b Excludes offspring mortalities that occurred following death of the dam; deaths assumed not treatment related.

##### Offspring Body Weight

Offspring body weights were available from two developmental studies (Iwai and Hoberman, 2014; Loveless et al., 2009) and a one-generation reproductive study (Loveless et al., 2009). In mice, offspring body weights were statistically significantly decreased at PND 0–7 in animals exposed gestationally (GD 6–18) to ≥100 mg/kg-day PFHxA ammonium salt. These effects were observed across two experimental cohorts with different but overlapping dose ranges (cohort 1 = 0, 100, 350, and 500 mg/kg-day; cohort 1 = 0, 7, 35, and 175 mg/kg-day). Although there is some variability in the magnitude of the dose response, consistent body weight deficits of ≥5% relative to control, a level of change that may be biologically significant during early development (U.S. EPA, 2012a, 1991), generally persisted to the end of lactation (Table 3-14). Some of this variability may be explained by differences in control body weights across the two cohorts or higher mortality of low body weight pups in the high dose groups. After weaning, some body weight deficits persisted, with females with the 350 mg/kg-day dose group showing a statistically significant reduction through the end of the experiment (PND 41) (Iwai and Hoberman, 2014).

Similar results were reported in two experiments with rats exposed to PFHxA sodium salt (Loveless et al., 2009). In the developmental study, fetal body weights (GD 21) of animals exposed gestationally (GD 6–20) to 500 mg/kg-day were decreased by 9% relative to controls, although this change was not statistically significant, but no effects were observed at the lower doses. In the one-generation reproductive study, a dose-related decrease (4%, 11%, and 18% decrease relative to controls for 20, 100, and 500 mg/kg-day, respectively, reaching statistical significance at the highest dose) was found in pup body weights across all dose groups at PND 0. Similar to results in the mouse study (Iwai and Hoberman, 2014), body weight deficits ≥5% relative to control were observed through the end of lactation (PND 21) in the 100 and 500 mg/kg-d dose groups, but resolved after weaning (Loveless et al., 2009).

Neither study reported treatment-related effects on body weight change (i.e., gains or losses) between weaning and the end of testing (PND 21–41 for mice; PND 21–60 for rats) (Iwai and Hoberman, 2014; Loveless et al., 2009). Results are presented in Figure 3-8 and Table 3-14.

Figure 3-8 Developmental effects on offspring body weight in mice exposed to PFHxA ammonium salt and rats exposed to PFHxA sodium salt (HAWC: PFHxA – Animal Toxicity Developmental Effects link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-developmental-effects-offs/))

Chart of developmental effects on offspring body weight.

Table 3-14 Percent change relative to control in offspring body weight due to PFHxA sodium or ammonium salt exposure in developmental oral toxicity studies

Postnatal date (GD 6–18) and sex; (Iwai and Hoberman, 2014) | Dose (mg/kg-d)
Postnatal date (GD 6–18) and sex; (Iwai and Hoberman, 2014) | 7 | 20 | 35 | 100 | 175 | 350 | 500
PND 0, male and female (combined) mice | 0 | | 0 | −6^*^ | −13^*^ | −13^*^ | −13^*^
PND 4, male and female (combined) mice | 0 | | 7 | −7 | −4^*^ | −27^*^ | −20^*^
PND 7, male and female (combined) mice | 0 | | 5 | −7 | 0 | −18^*^ | −11
PND 14, male and female (combined) mice | −1 | | 3 | −8 | 0 | −14 | −8
PND 20, male and female (combined) mice | −2 | | 6 | −11 | 2 | −20 | −12
PND 21, male mice | 3 | | 4 | −15^*^ | −1 | −18^*^ | −14
PND 28, male mice | 2 | | 3 | −10 | 0 | −10 | −8
PND 35, male mice | 1 | | 1 | −4 | −1 | −3 | −5
PND 41, male mice | 1 | | −1 | −2 | −3 | −3 | −4
PND 21, female mice | 0 | | 6 | −14^*^ | 1 | −17^*^ | −8
PND 28, female mice | 0 | | 4 | −9^*^ | −1 | −16^*^ | −7
PND 35, female mice | −1 | | 2 | −4 | −1 | −10^*^ | −7^*^
PND 41, female mice | −3 | | −1 | −4 | −3 | −8^*^ | −4
Fetal body weight, developmental exposure (GD 6–20) (Loveless et al., 2009)
GD 21, male and female (combined) rats | | −2 | | 0 | | | −9
Postnatal body weight, one-generation reproductive exposure (Loveless et al., 2009)
PND 0, male and female (combined) rats | | −4 | | −11 | | | −18^*^
PND 7, male and female (combined) rats | | 0 | | −6 | | | −17^*^
PND 14, male and female (combined) rats | | 3 | | −6 | | | −17^*^
PND 21, male and female (combined) rats | | 3 | | −5 | | | −18^*^
PND 28, male rats | | 2 | | −1 | | | −5
PND 35, male rats | | 1 | | −1 | | | −3
PND 39, male rats | | 2 | | −1 | | | −3
PND 60, male rats | | 2 | | −1 | | | −3
PND 28, female rats | | 1 | | −5 | | | −4
PND 35, female rats | | 1 | | −4 | | | −1
PND 39, female rats | | −1 | | −5 | | | −3
PND 60, female rats | | −1 | | −5 | | | −3

* Indicates instances where statistical significance (p < 0.05) compared to controls was reported by study authors; shaded cells represent doses not included in the individual studies.

##### Eye Opening

Potential effects of PFHxA exposure on eye opening were evaluated in a developmental study in mice (Iwai and Hoberman, 2014). On PND 14, Iwai and Hoberman (2014) reported a statistically significant delay in eye opening, with less than 50% of pups in the 350 and 500 mg/kg-day PFHxA ammonium salt exposure groups having reached this milestone compared to 85% among vehicle controls (see Figure 3-9). Although pup body weight changes were not statistically significantly at this timepoint, they were decrements of a magnitude considered to be potentially biologically significant (8%–14%) and some developmental landmarks are correlated with postnatal body weight gain (U.S. EPA, 2016c). Delays in eye opening persisted in the 350 and 500 mg/kg-day dose groups on PND 15 but were not statistically significant. Eye opening in mice typically occurs between PND 11 and PND 14, with full functionality a few days later (Brust et al., 2015). Delays in eye opening can have long-term impacts on vision by interfering with sensory input during the critical window of visual cortex development (Espinosa and Stryker, 2012; Wiesel, 1982). The results are summarized in Figure 3-9 and Table 3-15.

Figure 3-9 Developmental effects on eye opening (percent change relative to control) in mice exposed to PFHxA ammonium salt (HAWC: PFHxA – Animal Toxicity Developmental Eye Effects link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-developmental-effects-eye/))

Chart of developmental effects on eye opening.

Table 3-15 Percent change relative to control in eye opening due to PFHxA ammonium salt exposure in a developmental oral toxicity study

Study design and reference | Dose (mg/kg-d)
Study design and reference | 7 | 35 | 100 | 175 | 350 | 500
PND 13, male and female (combined) mice (Iwai and Hoberman, 2014) | −6 | 34 | −56 | −21 | −58 | −55
PND 14, male and female (combined) mice (Iwai and Hoberman, 2014) | 2 | 4 | −17 | −8 | −49^*^ | −39^*^
PND 15, male and female (combined) mice (Iwai and Hoberman, 2014) | 0 | 0 | −10 | −5 | −23 | −25
PND 16, male and female (combined) mice (Iwai and Hoberman, 2014) | 0 | 0 | −1 | 0 | −9 | −1

* Indicates instances where statistical significance (p < 0.05) compared to controls was reported by study authors.

##### Malformations and Variations

Potential effects of PFHxA exposure on fetal malformations and variations were evaluated in a single developmental study (Loveless et al., 2009). No treatment-related effects were found on fetal malformations or variations in rats following gestational (GD 6–20) exposure to up to 500 mg/kg-day PFHxA sodium salt.

#### Evidence Integration

The only available human study examining potential developmental effects was considered uninformative; therefore, there is indeterminate human evidence of developmental effects.

In animals, three high confidence studies reported in two publications examined developmental effects following maternal perinatal exposure to PFHxA salts (Iwai and Hoberman, 2014; Loveless et al., 2009). Treatment-related effects, including decreased offspring body weight, increased mortality, and delayed eye opening, were observed in mice following exposure to PFHxA ammonium salt at doses as low as 100 mg/kg-day (Iwai and Hoberman, 2014). Reductions in offspring body weight were also found in the one-generation reproductive and developmental studies in rats, although effects were less pronounced than those observed in mice. Animals in the reproductive cohort exposed throughout gestation and lactation showed body weight reductions that may be biologically significant (≥5%) at exposure to ≥100 mg/kg-day and statistically significant at 500 mg/kg-day that persisted to PND 21, whereas the developmental cohort was reduced (9%) only at the high dose (500 mg/kg-day).

In general, effects on development were greatest in magnitude from PND 0 to PND 7, suggesting that the early postnatal period might be a sensitive window for developmental effects associated with PFHxA exposure. Although the evidence base is small, the data are strengthened by coherent evidence across outcomes, consistency of effects on body weight across two species/studies, and the severity of some of the outcomes (e.g., increased offspring mortality). In addition, a similar pattern of effects on development (i.e., offspring body weight reductions and delays in developmental milestones) has been observed with other PFAS, including PFBS (U.S. EPA, 2021b) and PFBA (U.S. EPA, 2022a), providing additional support for these specific findings. Importantly, reduced growth during early life is associated with increased risk of developing adverse health effects in humans, including cardiovascular disease, type 2 diabetes, and early mortality in later life (Thompson and Regnault, 2011; Kajantie et al., 2005; Barker, 2004). Similarly, delays in eye opening can have lasting adverse impacts preventing visual input during a critical period of development for the visual cortex (Espinosa and Stryker, 2012; Wiesel, 1982).

The potential for maternal effects to act as a driver for the observed developmental effects was considered. In Iwai and Hoberman (2014), there was no effect on maternal body weight in either cohort. Some deaths were observed among the cohort 1 dams, but these did not appear to be dose related as there was aa similar incidence observed across controls and exposed groups. Reductions in maternal body weight were noted in the developmental study by Loveless et al. (2009). Dams exposed to 500 mg/kg-day from GD 6–20 showed a slight but statistically significant 5% decrease in total net body weight (i.e., terminal body weight minus the gravid uterine weight) and body weight gain on GD 21 (Loveless et al., 2009). In the one-generation reproductive study, Loveless et al. (2009) reported a statistically significant reduction in maternal weight gain in the highest dose group (500 mg/kg-day); however, this effect was limited to early gestation (GD 0–7). Importantly, there was no effect on maternal body weight gain over the entire gestational window (GD 0–21), nor was there any observed effects on total or net maternal body weights. Thus, the effects on offspring body weight in this study are not expected to be driven by maternal toxicity. Given this interpretation of an effect on development and based on the multiple adverse changes in pups, there is moderate animal evidence of developmental effects.

Overall, the currently available evidence indicates that PFHxA likely causes developmental effects in humans given sufficient exposure conditions (see Table 3-16).^6^ This judgment is based primarily on several high confidence, gestational exposure experiments in mice (and supportive findings in rats), with effects occurring after oral PFHxA exposure at ≥100 mg/kg-day. These findings are interpreted as relevant to humans in the absence of evidence to the contrary. This assumption is based on Guidelines for Developmental Toxicity Risk Assessment (U.S. EPA, 1991).

Table 3-16 Evidence profile table for developmental effects

Evidence stream summary and interpretation | | | | | Evidence integration summary judgment
Evidence from studies of exposed humans | | | | | ⊕⊕⊙; Evidence indicates (likely); Primary basis:; Three high confidence studies in rats and mice including gestational (rats and mice) and continuous one-generational reproductive (rats) exposures, generally observing effects at ≥100 mg/kg-d PFHxA ammonium or sodium salt.; Human relevance:; Without evidence to the contrary, effects in rats and mice are considered relevant to humans.; Cross stream coherence:; N/A (human evidence indeterminate).; - Susceptible populations and lifestages:; - The available evidence indicates that development may be a susceptible lifestage for exposure to PFHxA.
Studies and confidence | Factors that increase certainty | Factors that decrease certainty | Summary and key findings | Evidence stream judgment
- There were no informative human studies available from the PFHxA evidence base. | | | | ⊙⊙⊙; Indeterminate
Evidence from animal studies
Studies and confidence | Factors that increase certainty | Factors that decrease certainty | Summary and key findings | Evidence stream judgment
Offspring Mortality (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-developmental-effects-viab/); 2 high (https://hawc.epa.gov/summary/visual/assessment/100500070/animal-toxicology-study-evaluation/) confidence studies in rats and mice:; - GD 6–18 (mice); - 1-generation reproductive (rats) | - High confidence studies; - Concerning severity of effect – increased mortality | - Unexplained inconsistency across species | - Increased perinatal mortality at ≥350 mg/kg-d in mice | ⊕⊕⊙; Moderate; Developmental effects observed in multiple high confidence studies conducted in two species exposed to different PFHxA salts under different exposure scenarios. Effects on body weight were observed at doses that were not associated with offspring mortality or maternal toxicity.
Body Weight (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-developmental-effects-offs/); 3 high (https://hawc.epa.gov/summary/visual/assessment/100500070/animal-toxicology-study-evaluation/) confidence studies in rats and mice:; - GD 6–18 (mice); - GD 6–20 (rats); - 1-generation reproductive (rats) | - High confidence studies; - Consistency across studies and species; - Dose response observed in mouse study | - No factors noted | - Postnatal body weight decreased at ≥100 mg/kg-d in rats and mice; - Fetal body weight decreased at 500 mg/kg-d in rats
Eye Opening (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-developmental-effects-eye/); 1 high (https://hawc.epa.gov/summary/visual/assessment/100500070/animal-toxicology-study-evaluation/) confidence study in mice:; - GD 6–18 | - High confidence study | - No factors noted | - Eye opening was delayed in mice prenatally exposed to PFHxA ammonium salt at ≥350 mg/kg-d
Malformations and variations; 1 high (https://hawc.epa.gov/summary/visual/assessment/100500070/animal-toxicology-study-evaluation/) confidence study in rats:; - GD 6–20 | - High confidence study. | - No factors noted. | - No fetal malformations or variations observed at ≤500 mg/kg-d
Mechanistic evidence and supplemental information
Biological events or pathways | Summary of key findings, limitations, and interpretation | | | Evidence stream summary
- There were no informative mechanistic studies available from the PFHxA evidence base.

### 3.2.3 Renal Effects

#### Human

Three epidemiological studies investigated the relationship between PFHxA exposure and effects on the renal system. Two cross-sectional studies of adults in Korea and older adults in China (Zhang et al., 2019; Seo et al., 2018) were considered uninformative due to lack of consideration of confounding, including age and sex. The remaining study was a cross-sectional study of primarily government employees in China (Wang et al., 2019) and was classified as low confidence primarily due to significant concerns for reverse causality that could result if there is decreased elimination of PFAS with reduced renal function (this is also a concern for the uninformative studies). They observed a significant decrease in estimated glomerular filtration rate (eGFR) with higher serum PFHxA levels (β: −0.3 change in eGFR as mL/min/1.73 m^2^ per 1 ln-unit PFHxA [95% CI: −0.6, −0.01]). No association was observed with chronic kidney disease. Due to the potential for reverse causality and limited sensitivity due to narrow exposure contrast for PFHxA, there is substantial uncertainty in the results of this study. A summary of the study evaluations is presented in Figure 3-10, and additional details can be obtained by clicking the HAWC link (https://hawcprd.epa.gov/summary/visual/100500125/).

Figure 3-10 Study evaluation for human epidemiological studies reporting findings from PFHxA exposures (full details available by clicking HAWC link (https://hawcprd.epa.gov/summary/visual/100500125/))

Chart showing the study evaluation for human epidemiological studies related to PFHxA exposures.

#### Animal

Four short-term (28-day), subchronic, or chronic animal studies evaluated potential renal effects of PFHxA or PFHxA sodium salt in rats. Most of the outcome-specific study ratings were rated high confidence. For Chengelis et al. (2009b), limitations were identified that influenced some outcome-specific ratings. Specifically, histopathology was rated low confidence because of issues related to observational bias, endpoint sensitivity and specificity, and results presentation. Urinary biomarker outcomes in the same study were rated medium confidence because of results presentation (only qualitative results were reported). The results of the outcome-specific confidence judgments are summarized in Table 3-17, and full study evaluation details can be viewed by clicking the HAWC link (https://hawcprd.epa.gov/summary/visual/assessment/100500070/animal-toxicology-study-evaluation/).

Table 3-17 Renal endpoints for PFHxA and associated confidence scores from repeated-dose animal toxicity studies

Author (year) | Species, strain (sex) | Exposure design | Exposure route | Blood biomarkers | Urinary biomarkers | Histopathology | Organ weight
NTP (2018) | Rat, Harlan Sprague-Dawley (male and female) | Short term (28 d) | Gavage^a^; Male and female: 0, 62.5, 125, 250, 500, 1,000 mg/kg-d | ++ | NM | ++ | ++
Chengelis et al. (2009b) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | Subchronic (90 d) | Gavage^a^; Male and female: 0, 10, 50, 200 mg/kg-d | NR | + | − | ++
Loveless et al. (2009) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | Subchronic (90 d) | Gavage^b^; Male and female: 0, 20, 100, 500 mg/kg-d | ++ | ++ | ++ | ++
Klaunig et al. (2015) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | 2-yr cancer bioassay | Gavage^a^; Male: 0, 2.5, 15, 100 mg/kg-d; Female: 0, 5, 30, 200 mg/kg-d | ++ | ++ | ++ | NM

++ Outcome rating of high confidence; + outcome rating of medium confidence; − outcome rating of low confidence; NR, outcome not reported; NM, outcome not measured.

a,b Study evaluation for animal toxicological renal endpoints reported from studies with male and female rats receiving PFHxA^a^ or PFHxA sodium salt^b^ by gavage. Study evaluation details for all outcomes are available by clicking the HAWC link (https://hawcprd.epa.gov/summary/visual/100500177/).

##### Organ Weight

Increases in relative kidney weight were observed in both sexes in all three studies that reported this endpoint (NTP, 2018; Chengelis et al., 2009b; Loveless et al., 2009). There were statistically significant findings in male rat dose groups at PFHxA doses as low as 10 mg/kg-day in the subchronic study (Chengelis et al., 2009b). Except for the results from Chengelis et al. (2009b), effects on relative kidney weights generally showed a weak or no dose-response gradient (see Table 3-18). Craig et al. (2015) analyzed oral chemical exposure data extracted from subchronic and chronic rat studies and found a statistically significant correlation between absolute, but not relative, kidney weight, and kidney histopathology (even at doses where terminal body weights were decreased) for most chemicals (32/35) examined indicating that absolute kidney weight is more sensitive to the effects of chemical exposure than relative kidney weight. Absolute kidney weight was increased, but only in one of the three studies reporting on this endpoint (NTP, 2018), and only in female rats at the highest dose group (1,000 mg/kg-day). The decrease in relative, but not absolute, kidney weight could be explained by body weight gain decreases in the affected dose groups: 1,000 mg/kg-day male dose group (13% decrease) (NTP, 2018), 50 and 200 mg/kg-day male dose group [8%–11% decrease with similar trends in females (Chengelis et al., 2009b)], and 500 mg/kg-day male dose group (19% decrease, no change in females) (Loveless et al., 2009). Findings and full details of PFHxA effects on kidney weights can be viewed by clicking the HAWC link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-renal-effects-er-array/).

Table 3-18 Percent increase in relative and absolute kidney weight due to PFHxA exposure in short-term, subchronic, and chronic oral toxicity studies

Endpoint and reference | Dose (mg/kg-d)
Endpoint and reference | 10 | 20 | 50 | 62.5 | 100 | 125 | 200 | 250 | 500 | 1,000
Relative kidney weight; 28-d, female rat (NTP, 2018) | | | | −2 | | 0 | | 0 | 3 | 12^*^
Relative kidney weight; 28-d, male rat (NTP, 2018) | | | | 0 | | 2 | | 2 | 12^*^ | 19^*^
Relative kidney weight; 90-d, female rat (Chengelis et al., 2009b) | 1 | | 12^*^ | | | | 7
Relative kidney weight; 90-d, male rat (Chengelis et al., 2009b) | 8^*^ | | 7^*^ | | | | 9^*^
Relative kidney weight; 90-d, female rat (Loveless et al., 2009) | | −3 | | | 5 | | | | 16^*^
Relative kidney weight; 90-d, male rat (Loveless et al., 2009) | | 0 | | | 11 | | | | 17^*^
Absolute kidney weight, right; 28-d, female rat (NTP, 2018) | | | | −1 | | 1 | | 1 | 1 | 9^*^
Absolute kidney weight, right; 28-d, male rat (NTP, 2018) | | | | 2 | | 0 | | 1 | 8 | 3
Absolute kidney weight; 90-d, female rat (Chengelis et al., 2009b) | 0 | | 7 | | | | 4
Absolute kidney weight; 90-d, male rat (Chengelis et al., 2009b) | −1 | | −6 | | | | 2
Absolute kidney weight; 90-d, female rat (Loveless et al., 2009) | | 0 | | | 1 | | | | 14
Absolute kidney weight; 90-d, male rat (Loveless et al., 2009) | | 0 | | | 8 | | | | 4

* Indicates instances where statistical significance (p < 0.05) compared to controls was reported by study authors; shaded cells represent doses not included in the individual studies.

##### Histopathology

Renal histopathological subchronic findings were qualitatively reported as null (Chengelis et al., 2009b; Loveless et al., 2009). The short-term study findings included increases in minimal chronic progressive nephropathy (CPN) that were significant (incidence 8/10) in the 1,000 mg/kg-day female dose group (see Figure 3-11) (NTP, 2018), consistent with increased absolute kidney weight. Male renal histopathological findings from the chronic study were also null, whereas findings for female rats included increased papillary necrosis (17/70 vs. 0/60 in controls) and tubular degeneration (7/70 vs. 1/60 in controls) in the highest dose group 200 mg/kg-day (Klaunig et al., 2015). Full details are available by clicking the HAWC link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-kidney-histopathology-inci/).

Figure 3-11 Animal toxicological renal histopathology after PFHxA exposure (full details available by clicking the HAWC link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-kidney-histopathology-inci/))

Findings from the subchronic studies were reported as null and not included in the above visualization.

Chart showing animal toxicological renal histopathology following PFHxA exposure. Chart is blurred and hard to read.

##### Blood and Urinary Biomarkers

Blood biomarkers of renal function were inconsistent across study designs and exposure durations. Both creatinine and blood urea nitrogen (BUN) are removed from the blood by the kidneys and often used as indicators of kidney function. Creatinine is a waste product of creatine metabolism (primarily in muscle), and BUN is a waste product of protein metabolism in the liver. No observations of changes in urea nitrogen or creatinine were reported from Chengelis et al. (2009b) and Klaunig et al. (2015). In the short-term study (NTP, 2018), BUN was unchanged in both sexes in all dose groups. Changes in creatinine were inconsistent across sexes with null findings in females, whereas a 13% decrease (p < 0.05) was found in the male 500 mg/kg-day dose group (NTP, 2018). In a subchronic study, Loveless et al. (2009) reported a sex-specific increase in BUN in the male 200 mg/kg-day dose group, whereas creatinine was decreased in both male and female rats dosed with 200 mg/kg-day PFHxA sodium.

Urinalysis findings included total urine volume and other measures of urine concentrating ability (e.g., specific gravity, urobiloginen). The urinalysis findings were more consistent than the blood biomarkers, but still difficult to interpret as adverse or nonadverse. Urinalysis findings were not measured in the short-term study (NTP, 2018) and were reported as null in a subchronic study (Chengelis et al., 2009b). Findings from the other subchronic study (Loveless et al., 2009) identified changes in urine concentration reflected as decreased (50%–88%) urine protein combined with increased (207%–300%) total urine volume in males and females in the 500 mg/kg-day dose groups. Coherent with increased urine volume, osmolality was decreased (47%, p < 0.05), but only in the male 500 mg/kg-day dose group (Loveless et al., 2009). Urobilinogen and pH findings were null in both male and females in the subchronic study (Loveless et al., 2009). Findings from the chronic study lacked consistency between sexes and did not exhibit a clear dose-response relationship (Klaunig et al., 2015). Specifically, total urine volume was increased in the female 200 mg/kg-day dose group and null in all male dose groups. Urine specific gravity was increased (p < 0.05) in the male 15 mg/kg-day dose group and similar to controls in the 100 mg/kg-day dose group, although specific gravity was increased (p < 0.05) in the female 200 mg/kg-day dose group. Urine pH was low in males (compared to controls) only in the 100 mg/kg-day dose groups at 26 and 52 weeks (Klaunig et al., 2015). Total urine volume findings were null in males, whereas an increase was found in female rats from the 200 mg/kg-day dose group at 26 weeks that returned to control levels at 52 weeks study duration (Klaunig et al., 2015). Findings are summarized in Figure 3-12, and full details are available in the HAWC link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-renal-effects-serum-and-ur/).

Figure 3-12 PFHxA Effects on blood and urine biomarkers of renal function (full details available by clicking the HAWC link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-renal-effects-serum-and-ur/))

The dashed blue line divides blood (top) from urinary biomarkers. Note that blood urea nitrogen and creatinine were described as null, but findings were not quantitatively reported.

Chart showing blood and urine biomarkers on renal function. Chart is blurred and hard to read.

#### Evidence Integration

The human evidence was limited to a single low confidence study reporting an inverse association between PFHxA exposure and eGFR, although notable uncertainty in this result exists due to potential for reverse causality. Based on these data, there is indeterminate human evidence for renal effects.

The evidence base for renal effects in experimental animals was drawn from generally high confidence studies including one short-term, two subchronic studies, and one chronic study. Findings were, in general, null except for histopathology and some urinary biomarkers. Kidney histopathology was the most significant finding in the short term and chronic studies. In the short-term study, increased incidence of CPN was observed in female rats at the highest dose (1,000 mg/kg-day PFHxA) and consistent with increased absolute kidney weight (females only). Histopathological findings were null in both subchronic studies at doses up to 500 mg/kg-day. In the chronic study, the incidence of papillary necrosis and tubular degeneration were increased in females compared to controls at the highest dose (200 mg/kg-day) that is twice the highest dose received by male rats in the chronic study. Some changes occurred in urinary biomarkers (decreased urine pH, increased urine volume) and potentially correlated changes were observed in female histopathology in the chronic study. However, inconsistencies across studies at similar observation times and doses were notable. Based on these results, there is slight animal evidence of renal effects.

Overall, the currently available evidence is inadequate to assess whether PFHxA may causes renal effects in humans (see Table 3-19).

Table 3-19 Evidence profile table for renal effects

Evidence stream summary and interpretation | | | | | Evidence integration summary judgment
Evidence from studies of exposed humans | | | | | ⊙⊙⊙; Evidence inadequate; Primary basis:; Indeterminate evidence in humans and animal evidence is largely null or lacking biological coherence, overall effects not clearly adverse; Human relevance:; Without evidence to the contrary, effects in rats are considered relevant to humans; Cross-stream coherence:; N/A (human evidence indeterminate); Susceptible lifestages:; - No evidence to inform
Studies and confidence | Factors that increase certainty | Factors that decrease certainty | Summary and key findings | Evidence stream judgment
Kidney Function; 1 low (https://hawcprd.epa.gov/study/100517563/) confidence study | - No factors noted | - Low sensitivity; - Potential for reverse causality | - Weak association of PFHxA with decrease in estimated eGFR | ⊙⊙⊙; Indeterminate
Evidence from animal studies
Studies and confidence | Factors that increase certainty | Factors that decrease certainty | Summary and key findings | Evidence stream judgment
Organ Weight (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-renal-effects-er-array/); 3 high (https://hawcprd.epa.gov/summary/visual/100500177/) confidence studies in adult rats:; - 28-d; - 90-d (2 studies) | - Consistent increases, all studies | - Weak Weak/no dose response | - Increased relative kidney weight at ≥10 mg/kg-d.; - Increase absolute kidney weight at 1,000 mg/kg-d; 28-d study, females only | ⊕⊙⊙; Slight; Findings of adversity were considered uncertain based on lack of coherence between effects (organ weight, histopathology, blood, and urine biomarkers) inconsistency between sexes, and lack of coherence across exposure designs
Histopathology (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-kidney-histopathology-inci/); 3 high (https://hawcprd.epa.gov/summary/visual/100500177/) confidence studies in adult rats:; - 28-d; - 90-d; - 2-yr; 1 low (https://hawcprd.epa.gov/summary/visual/100500177/) confidence study in adult rats:; - 90-d | - Large magnitude of effect, up to 24.3% for papillary necrosis; up to 80% for chronic progressive nephropathy | - No factors noted | - Increased incidence papillary necrosis, tubular degeneration, chronic progressive nephropathy at ≥200 mg/kg-d; female rats only, 28-d and chronic studies
Blood Biomarkers (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-renal-effects-serum-and-ur/); 4 high (https://hawcprd.epa.gov/summary/visual/100500177/) confidence studies in adult rats:; - 28-d; - 90-d (2 studies); - 2-yr | - No factors noted | - Lack of coherence with other histopathological findings; chronic study; - Lack of consistent effect across studies | - Increased BUN at 500 mg/kg-d; males only, 90-d study.; - Decreased creatinine at ≥500 mg/kg-d), both sexes, 1 subchronic study; - Decreased creatine at 1,000 mg/kg-d; males only, 28-d study; - No treatment related creatinine kinase findings; both sexes, 28-d study
Urinary Biomarkers (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-renal-effects-serum-and-ur/); 3 high (https://hawcprd.epa.gov/summary/visual/100500177/) confidence studies in adult rats:; - 28-d; - 90-d; - 2-yr; 1 medium (https://hawcprd.epa.gov/summary/visual/100500177/) confidence study in adult rats:; - 90-d | - Coherence of urine protein, urine volume, urine specific gravity, and decreased osmolality | - Lack of coherence with histopathological findings. | - Decreased osmolality 500 mg/kg-d; males only, 1 subchronic study; - Decreased urine protein and increased urine volume in at 500 kg/kg-d; both sexes, 1 subchronic study; - Increased total urine volume at ≥200 mg/kg-d; both sexes — 1 subchronic study, females only, 1 2-yr study; - Decreased urine pH at 100 mg/kg-d; males only, 1 2-yr study; - No treatment related findings for urobilinogen; both sexes, 1 subchronic study and 1 2-yr study
Mechanistic evidence and supplemental information
Biological events or pathways | Primary evidence evaluated; Key findings, interpretation, and limitations | | | Evidence stream summary
Molecular; Events—Oatp1a1 | Key findings and interpretation:; Sex hormone-dependent regulation of Oatp1a1 mRNA and protein level (see Section 3.1.4). | | | Sex-specific Oatp1a1 expression appears to lead to sex-specific PFHxA elimination, leading to longer PFHxA half-life in male rats compared with females, which may explain sex-specific renal findings.

### 3.2.4 Hematopoietic Effects

Hematology is a subgroup of clinical pathological parameters concerned with morphology, physiology, and pathology of blood and blood-forming tissues. Hematological parameters are measured using blood tests such as complete blood counts (CBC) and a clinical chemistry panel. The CBC is a blood test that measures (red blood cells, white blood cells, hemoglobin, hematocrit, and platelets), whereas the clinical chemistry panel measures the proteins, enzymes, chemicals, and waste products in the blood. Hematological measures, when evaluated together and with information on other biomarkers, are informative diagnostic tests for blood-forming tissues (i.e., bone marrow, spleen, liver) and organ function. In animals, blood tests are influenced by the feeding protocol, blood collection site, animal age, and other factors.

#### Human Studies

One human study (Jiang et al., 2014) evaluated blood counts in samples drawn from a population of 141 pregnant women living in Tianjin, China. The study was considered uninformative, however, due to lack of consideration of confounding, including age, which is expected to substantially bias the results. Full study evaluation for Jiang et al. (2014) is available by clicking the HAWC link (https://hawcprd.epa.gov/rob/study/100517539/).

#### Animal Studies

Several animal toxicological studies were available that assessed hematopoietic parameters including a high confidence short-term study (NTP, 2018), high confidence (Chengelis et al., 2009b) and high confidence (Loveless et al., 2009) subchronic studies, and a high confidence chronic study (Klaunig et al., 2015). Cell counts for the blood components associated with immune system responses are summarized under in Immune Effects, see Section 3.2.8. Study findings are discussed below and summarized in Table 3-20 (full details are available by clicking the HAWC link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-hematology-effects-eryth/)), and summary details are available in PFHxA Tableau (https://public.tableau.com/profile/literature.inventory#!/vizhome/PerfluorohexanoicAcidPFHxAEvidenceMapVisualization/AnimalStudies) visualization.

Table 3-20 Hematopoietic endpoints for PFHxA and associated confidence scores from repeated-dose animal toxicity studies

Author (year) | Species, strain (sex) | Exposure design | Exposure route and dose range | Hematology and hemostasis
NTP (2018) | Rat, Harlan Sprague-Dawley (male and female) | Short term (28 d) | Gavage^a^; Male and female: 0, 62.5, 125, 250, 500, 1,000 mg/kg-d | ++
Chengelis et al. (2009b) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | Subchronic (90 d) | Gavage^a^; Male and female: 0, 10, 50, 200 mg/kg-d | ++
Loveless et al. (2009) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | Subchronic (90 d) | Gavage^b^; Male and female: 0, 20, 100, 500 mg/kg-d | ++
Klaunig et al. (2015) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | 2-yr cancer bioassay | Gavage^a^; Male: 0, 2.5, 15, 100 mg/kg-d; Female: 0, 5, 30, 200 mg/kg-d | ++

++ Outcome rating of high confidence.

a,b Study evaluation for animal toxicological hematopoietic endpoints reported from studies with male and female rats receiving PFHxA^a^ or PFHxA sodium salt^b^ by gavage. Study evaluation details for all outcomes are available by clicking the HAWC link (https://hawcprd.epa.gov/summary/visual/100500177/).

##### Hematology

Several findings were consistent (i.e., decreased red blood cells [RBCs], hematocrit, and hemoglobin) across studies and study designs that, when interpreted together, suggest PFHxA-related adverse hematological effects such as anemia (see Figure 3-13). Indications were also present that red blood cells were swollen and made up a larger proportion of the blood volume (increased mean cell volume [MCV, a measure of the average red blood cell size]). These changes were correlated with potential secondary erythrogenic responses to PFHxA exposure including increased reticulocyte (immature RBCs) counts that were consistently increased >10% across study designs and exposure durations, including the chronic study Klaunig et al. (2015) where the highest dose levels were 2–5 times lower than those tested in the subchronic studies. Specifically, a dose-responsive decrease occurred in red blood cells (see Table 3-21), hematocrit (see Table 3-22), and hemoglobin (see Table 3-23) in the short-term study with decreases at doses ranging from 62.5 mg/kg-day in male rats to 250 mg/kg-day in female rats (NTP, 2018). These findings also were observed in both subchronic studies in the highest dose groups [200 mg/kg-day in males only (Chengelis et al., 2009b) and 500 mg/kg-day in both sexes (Loveless et al., 2009)]. Of note, decreases in both hemoglobin and hematocrit were 1.5–2-fold greater in the subchronic study (Loveless et al., 2009) than in the short-term study (NTP, 2018) for both males and females at the same dose (500 mg/kg-day).

Findings from the chronic study (Klaunig et al., 2015) were generally null or observed at dose levels ≥100 mg/kg-day (100 mg/kg-day in males and 200 mg/kg-day in females) at 25 and 51 weeks. Quantitative measures of hematology beyond 52 weeks in the chronic study might be complicated due to natural diseases occurring in rodents and test variability leading to decreased sensitivity and increasing variability with the results (AACC, 1992). Klaunig et al. (2015) did, however, qualitatively evaluate blood and reported no PFHxA treatment effects on blood smear morphology. Loveless et al. (2009) also evaluated blood smears up to test day 92 with PFHxA sodium salt exposure and noted nucleated blood cells in smears indicative of bone marrow damage or stress, but only for one female and one male.

Figure 3-13 Hematological findings (HCT, HGB, and RBC) in rats exposed by gavage to PFHxA or PFHxA sodium salt (full details available by clicking the HAWC link (https://hawc.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-hematopoietic-effects-rbc/))

HCT = hematocrit; HGB = hemoglobin; RBC = red blood cells.

Chart showing hematological findings in rats exposed to PFHxA or PFHxA sodium salt. Chart is blurred and hard to read.

Table 3-21 Percent change in red blood cells due to PFHxA exposure in short-term, subchronic, and chronic oral toxicity studies

Study design and reference | Dose (mg/kg-d)
Study design and reference | 2.5 | 5 | 10 | 15 | 20 | 30 | 50 | 62.5 | 100 | 125 | 200 | 250 | 500 | 1,000
28-d, female rat (NTP, 2018) | | | | | | | | −1 | | 2 | | −7 | −10^*^ | −26^*^
28-d, male rat (NTP, 2018) | | | | | | | | −5 | | −5 | | −9^*^ | −23^*^ | −48^*^
90-d, female rat (Chengelis et al., 2009b) | | | −1 | | | | −3 | | | | −8^*^
90-d, male rat (Chengelis et al., 2009b) | | | −1 | | | | 0 | | | | −8^*^
90-d, female rat (Loveless et al., 2009) | | | | | 2 | | | | 0 | | | | −18^*^
90-d, male rat (Loveless et al., 2009) | | | | | 1 | | | | −5 | | | | −31^*^
2-yr, female rat (Klaunig et al., 2015),; Wk 25 | | 4 | | | | −2 | | | | | −1
2-yr, male rat (Klaunig et al., 2015),; Wk 25 | −3 | | | −3 | | | | | −4
2-yr, female rat (Klaunig et al., 2015),; Wk 51 | | 1 | | | | 0 | | | | | −8^*^
2-yr, male rat (Klaunig et al., 2015),; Wk 51 | −4 | | | −6 | | | | | −4
2-yr, female rat (Klaunig et al., 2015),; Wk 104 | | −1 | | | | −2 | | | | | 1
2-yr, male rat (Klaunig et al., 2015),; Wk 104 | −7 | | | −1 | | | | | −8

* Indicates instances where statistical significance (p < 0.05) compared to controls was reported by study authors; shaded cells represent doses not included in the individual studies.

The red blood cell mass parameter (MCHC, the average weight of hemoglobin in a specified volume of red blood cells) was decreased in both sexes in the short-term (NTP, 2018) and subchronic studies (Loveless et al., 2009) (see Figure 3-14). Null findings for MCHC were observed in the other subchronic study (Chengelis et al., 2009b) and the chronic study (Klaunig et al., 2015), consistent with MCHC findings at similar dose levels in the short-term (NTP, 2018) and subchronic studies (Loveless et al., 2009). MCV, a measure of average blood volume of RBCs was increased in both a short-term and a subchronic study (NTP, 2018; Loveless et al., 2009).

Figure 3-14 Hematological findings (MCH, MCHC, and MCV) in rats exposed by gavage to PFHxA or PFHxA sodium salt (full details available by clicking the HAWC link (https://hawc.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-hematopoietic-effects-mchc/))

MCH = mean cell hemoglobin; MCHC = mean cell hemoglobin concentration; MCV = mean cell volume.

Chart showing PFHxA hematological findings in exposed rats.

Table 3-22 Percent change in hematocrit due to PFHxA exposure in short-term, subchronic, and chronic oral toxicity studies

Study design and reference | Dose (mg/kg-d)
Study design and reference | 2.5 | 5 | 10 | 15 | 20 | 30 | 50 | 62.5 | 100 | 125 | 200 | 250 | 500 | 1,000
28-d, female rat (NTP, 2018) | | | | | | | | −1 | | 0 | | −7^*^ | −8^*^ | −17^*^
28-d, male rat (NTP, 2018) | | | | | | | | −4 | | −6^*^ | | −6^*^ | −17^*^ | −30^*^
90-d, female rat (Chengelis et al., 2009b) | | | 0 | | | | −5 | | | | −6
90-d, male rat (Chengelis et al., 2009b) | | | −3 | | | | −3 | | | | −8
90-d, female rat (Loveless et al., 2009) | | | | | 1 | | | | 0 | | | | −13^*^
90-d, male rat (Loveless et al., 2009) | | | | | 0 | | | | −6 | | | | −31^*^
2-yr, female rat (Klaunig et al., 2015),; Wk 25 | | 3 | | | | 0 | | | | | 0
2-yr, male rat (Klaunig et al., 2015),; Wk 25 | −1 | | | −3 | | | | | −3
2-yr, female rat (Klaunig et al., 2015),; Wk 51 | | 1 | | | | 0 | | | | | −4
2-yr, male rat (Klaunig et al., 2015),; Wk 51 | −5 | | | −4 | | | | | −3
2-yr, female rat (Klaunig et al., 2015),; Wk 104 | | 0 | | | | −1 | | | | | 1
2-yr, male rat (Klaunig et al., 2015),; Wk 104 | −9 | | | −5 | | | | | −8

* Indicates instances where statistical significance (p < 0.05) compared to controls was reported by study authors;shaded cells represent doses not included in the individual studies.

Table 3-23 Percent change in hemoglobin due to PFHxA exposure in short-term, subchronic, and chronic oral toxicity studies

Study design and reference | Dose (mg/kg-d)
Study design and reference | 2.5 | 5 | 10 | 15 | 20 | 30 | 50 | 62.5 | 100 | 125 | 200 | 250 | 500 | 1,000
28-d, female rat (NTP, 2018) | | | | | | | | 0 | | −1 | | −6^*^ | −8^*^ | −19^*^
28-d, male rat (NTP, 2018) | | | | | | | | −3 | | −5^*^ | | −6^*^ | −19^*^ | −40^*^
90-d, female rat (Chengelis et al., 2009b) | | | 1 | | | | −3 | | | | −6
90-d, male rat (Chengelis et al., 2009b) | | | −1 | | | | −1 | | | | −8
90-d, female rat (Loveless et al., 2009) | | | | | 1 | | | | 0 | | | | −15^*^
90-d, male rat (Loveless et al., 2009) | | | | | 1 | | | | −71 | | | | −36^*^
2-yr, female rat (Klaunig et al., 2015),; Wk 25 | | 3 | | | | 1 | | | | | −1
2-yr, male rat (Klaunig et al., 2015),; Wk 25 | −1 | | | −2 | | | | | −3
2-yr, female rat (Klaunig et al., 2015),; Wk 51 | | 1 | | | | 0 | | | | | −5 *
2-yr, male rat (Klaunig et al., 2015),; Wk 51 | −6 | | | −5 | | | | | −3
2-yr, female rat (Klaunig et al., 2015),; Wk 104 | | 0 | | | | 0 | | | | | −1
2-yr, male rat (Klaunig et al., 2015),; Wk 104 | −9 | | | −4 | | | | | −9

* Indicates instances where statistical significance (p < 0.05) compared to controls was reported by study authors; shaded cells represent doses not included in the individual studies.

Increased reticulocyte (immature RBCs formed during the erythroid regenerative process) counts were consistently found across all four animal toxicological studies (see Table 3-24 and Figure 3-15) and correlated with decreases in RBCs. PFHxA treatment-related increases in reticulocyte counts were potentially a compensatory biological response to the PFHxA anemia effect. Reticulocytes were increased (>10%) across all study designs and exposure durations at 200 mg/kg-day (Klaunig et al., 2015; Chengelis et al., 2009b), 250 mg/kg-day (NTP, 2018), or 500 mg-kg/day (Loveless et al., 2009). Reticulocyte measures were also available from Klaunig et al. (2015), where increases were identified only in the high dose (200 mg/kg-day) female rat group. The observation of increased reticulocytes was coherent with histological findings of increased splenic extramedullary hematopoiesis and bone marrow erythroid hyperplasia incidence in both the males and females dosed with 500 mg/kg-day (NTP, 2018; Loveless et al., 2009) (summary details are available in PFHxA Tableau (https://public.tableau.com/profile/literature.inventory#!/vizhome/PFHxAforTableau/Story1) visualization). Collectively, the histological findings considered together with red blood cell parameters suggest PFHxA interacts with the erythropoietic pathways including outcomes such as anemia that can lead to compensatory erythrogenic responses in the bone marrow and spleen.

Figure 3-15 Hematological findings (reticulocytes) in rats exposed by gavage to PFHxA or PFHxA sodium salt (full details available by clicking the HAWC link (https://hawc.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-hematopoietic-effects-reti/))

Chart showing hematological findings in rats exposed to PFHxA or PFHxA sodium salt.

Table 3-24 Percent change in reticulocytes due to PFHxA exposure in short-term, subchronic, and chronic oral toxicity studies

Study design and reference | Dose (mg/kg-d)
Study design and reference | 2.5 | 5 | 10 | 15 | 20 | 30 | 50 | 62.5 | 100 | 125 | 200 | 250 | 500 | 1,000
28-d, female rat (NTP, 2018) | | | | | | | | −5 | | −15 | | 15 | 152^*^ | 356^*^
28-d, male rat (NTP, 2018) | | | | | | | | 0 | | −2 | | 20 | 89^*^ | 223^*^
90-d, female rat (Chengelis et al., 2009b) | | | −7 | | | | −13 | | | | 80^*^
90-d, male rat (Chengelis et al., 2009b) | | | −5 | | | | −13 | | | | 59^*^
90-d, female rat (Loveless et al., 2009) | | | | | 7 | | | | 13 | | | | 181^*^
90-d, male rat (Loveless et al., 2009) | | | | | −14 | | | | −4 | | | | 210^*^
2-yr, female rat (Klaunig et al., 2015),; Wk 25 | | −5 | | | | 11 | | | | | 26^*^
2-yr, male rat (Klaunig et al., 2015),; Wk 25 | −5 | | | 0 | | | | | 15
2-yr, female rat (Klaunig et al., 2015),; Wk 51 | | −25 | | | | −6 | | | | | 56^*^
2-yr, male rat (Klaunig et al., 2015),; Wk 51 | 21 | | | 71 | | | | | 43
2-yr, female rat (Klaunig et al., 2015),; Wk 104 | | 6 | | | | 19 | | | | | 26^*^
2-yr, male rat (Klaunig et al., 2015),; Wk 104 | 21 | | | −6 | | | | | 29

* Indicates instances where statistical significance (p < 0.05) compared to controls was reported by study authors; shaded cells represent doses not included in the individual studies.

##### Hemostasis

Hemostasis findings included platelet counts, prothrombin time, and activated partial thromboplastin time. Clotting times measured by Chengelis et al. (2009b) and Klaunig et al. (2015) could be complicated because blood samples were collected from the retro-orbital sinus, a technique not recommended because it leads to prolonged clotting times that might not be reliable; thus, these endpoints were considered uninformative and are not discussed further. Findings of statistically significant increased (p < 0.05) platelets were observed in the short-term (NTP, 2018) and subchronic (Chengelis et al., 2009b; Loveless et al., 2009) studies in males and females dosed with 500 mg/kg-day dose (see Figure 3-16). Other hemostasis measures that included activated partial thromboplastin time (APTT) and prothrombin time (PT, a functional measure of a subset of clotting factors that contribute to APTT) were decreased inconsistently across sexes in one subchronic study (Loveless et al., 2009). PT was decreased in male dose groups receiving ≥20 mg/kg-day, whereas APTT was decreased in the 500 mg/kg-day female rat dose group. The observed increase in platelets and decreased clotting time (along with increased reticulocytes) were coherent changes indicative of an erythropoietic response in the bone marrow, suggesting bone marrow was not adversely affected by PFHxA exposure.

Figure 3-16 Hemostasis findings in rats exposed by gavage to PFHxA or PFHxA sodium salt (full details available by clicking the HAWC link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-hematology-effects-hemosta/))

Chart showing hemostatis findings in rats exposed to PFHxA or PFHxA sodium salt.

#### Evidence Integration

The only available human study examining potential hematopoietic effects was considered uninformative; therefore, there is indeterminate human evidence of hematopoietic effects.

Collectively, the animal toxicological information provided coherent evidence indicative of macrocytic anemia (characterized by low hemoglobin and large red blood cells) that is consistent across multiple laboratories and experimental designs. Findings informing the overall judgment included consistent observations of decreased red blood cells, hematocrit, and hemoglobin at doses as low as 200 mg/kg-day generally in both sexes (summary level details are available in the Tableau link (https://public.tableau.com/app/profile/literature.inventory/viz/PerfluorohexanoicAcidPFHxAEvidenceMapVisualization/AnimalStudies)). This finding was considered an adverse response to PFHxA exposure and correlated with a compensatory increase in reticulocytes, an indicator of erythroid cell regeneration supported by histological findings of splenic extramedullary hematopoiesis and bone marrow erythroid hyperplasia. The responses across hematologic parameters in the chronic study (Klaunig et al., 2015) were only observed at the highest dose (200 mg/kg-day) in females. However, the highest dose (200 mg/kg-day in females, 100 mg/kg-day in males) in Klaunig et al. (2015) was at or lower than the observed effect level in the other available short term and subchronic studies. Further, the null responses at lower doses (2.5, 15, and 100 mg/kg-day in male rats; 5 and 30 mg/kg-day in female rats) are consistent with null responses in hematologic endpoints at similar dose levels in the short term and subchronic studies. Overall, these collective erythroid responses provide evidence for PFHxA treatment-related effects on erythropoiesis in animals.

Based on these data, there is robust animal evidence of hematopoietic effects. Effects on red blood cell parameters including decreased hemoglobin, decreased red blood cells, and increased reticulocytes are consistent across both subchronic and chronic studies in the 200 mg/kg-day dose groups. The animal evidence came from studies using the same outbred Crl:CD(SD) rat model originating from the same location and supplier that made available clinical hematology parameters indicating no sex difference in the parameters reported here (https://www.criver.com/sites/default/files/Technical%20Resources/Clinical%20Pathology%20Data%20for%20North%20American%20CD%20Rat%20Colonies%20for%20January%202006%20-%20December%202011.pdf). Given species conservation between rodent models it was assumed that rat hematology was similar to that of the mouse where there are some hematologic differences between humans, including smaller erythrocytes, higher percentage of circulating reticulocytes (or polychromasia), physiologic splenic hematopoiesis and iron storage, and more numerous and shorter-lived erythrocytes and platelets (O’Connell et al., 2015). These differences could explain the possible regenerative response in the spleen and bone and the increase in reticulocytes (i.e., erythrogenesis and RBC turnover more rapid in rodent versus human). Therefore, while some uncertainty around the human relevance of rodent hematopoietic findings exists, these species-specific differences were controlled for in the experimental design.

Based on indeterminate evidence in humans and robust animal evidence with potentially uncertain human relevance, the currently available evidence indicates that PFHxA likely causes hematopoietic effects in humans given sufficient exposure conditions (see Table 3-25).^7^ This conclusion is based on four high confidence studies in rats showing consistent (across durations and study types) and coherent effects (across various outcome measures of hematopoietic function), generally at ≥200 mg/kg-day following short-term (28-day), subchronic (90-day), or chronic (2-year) exposures.

Table 3-25 Evidence profile table for hematopoietic effects

Evidence stream summary and interpretation | | | | | Evidence integration summary judgment
Evidence from studies of exposed humans | | | | | ⊕⊕⊙; Evidence indicates (likely); Primary basis:; Four high confidence studies in rats ranging from short term to chronic exposure durations, in both sexes, generally at ≥200 mg/kg-d; Human relevance:; Some species differences between human and rodent hematology exist, but these are not interpreted to impact judgments on the collection of rodent findings specific to PFHxA.; Cross-stream coherence:; N/A (human evidence indeterminate); Susceptible populations and lifestages:; No evidence to inform
Studies and confidence | Factors that increase certainty | Factors that decrease certainty | Summary and key findings | Evidence stream judgment
- There were no informative human studies available from the PFHxA evidence base. | | | | ⊙⊙⊙; Indeterminate
Evidence from animal studies
Studies and confidence | Factors that increase certainty | Factors that decrease certainty | Summary and key findings | Evidence stream judgment
Hematology (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-hematology-effects-eryth/); 4 high (https://hawcprd.epa.gov/summary/visual/100500177/) confidence studies in adult rats:; - 28-d; - 90-d (2 studies); - 2-yr | - Consistent changes (decreases in hematocrit, hemoglobin, red blood cells, and MCHC and increases in reticulocytes, MCV, and MCH) across studies; - Coherence of red blood cells, HCT, and HGB and reticulocytes; - Large magnitude of effect as high as 356% for reticulocytes; - High confidence studies | - No factors noted | - Decreased red blood cells, hematocrit, and hemoglobin at ≥62.5 mg/kg-d; both sexes; - Increased MCH and MCV at ≥250; males more sensitive; - Increased reticulocytes at ≥200 mg/kg-d; both sexes, all studies; - Coherence of red blood cells and reticulocytes with splenic extramedullary hematopoiesis and bone marrow erythroid hyperplasia | ⊕⊕⊕⊕; Robust; Findings considered adverse based on coherent evidence that was consistent across multiple laboratories and experimental designs. Consistent findings of decreased red blood cells, hematocrit, and hemoglobin at ≥200 mg/kg-d coherent with erythroid cell regeneration
Hemostasis (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-hematology-effects-hemosta/); 4 high (https://hawcprd.epa.gov/summary/visual/100500177/) confidence studies in adult rats:; - 28-d; - 90-d (2 studies); - 2-yr | - Consistent treatment related effect on platelet levels; - Consistency across study designs; - High confidence studies | - No factors noted | - Increased platelet levels ≥10 mg/kg-d; both sexes, 1 28-d, 2 90-d studies; - Decreased activated partial thromboplastin (APTT) at ≥20 mg/kg-d; males only, 1 90-d study; - Decreased prothrombin (PT) time at 500 mg/kg-d; males only, 1 90-d study
Mechanistic evidence and supplemental information
Biological events or pathways | Species or model systems | Key findings, limitations, and interpretation | | Evidence stream summary
- No informative studies identified.

### 3.2.5 Endocrine Effects

#### Human

##### Thyroid Hormones

Two studies examined the association between PFHxA exposure and thyroid hormones in humans (see Figure 3-17). One was considered uninformative due to lack of consideration of confounding, including age, sex, and other factors which is expected to substantially impact the results (Seo et al., 2018). The other study was a cross-sectional study of the general population in China and was considered low confidence (Li et al., 2017) due to concerns around participant selection, outcome measures, consideration of confounding, and decreased sensitivity. Regarding the latter concern, the exposure levels were low and contrast narrow in Li et al. (2017) (median [range]: 0.01 [<LOD−1.1]) and 47% of samples were below the LOD. Among participants without thyroid disease, inverse associations with free T3 and thyroid stimulating hormone (TSH) were reported, with TSH being statistically significant (Pearson correlation coefficient = −0.27, p < 0.01). No association was observed with free T4. Total T4 and T3 were not measured in this study.

Figure 3-17 Study evaluation for human epidemiologic studies reporting toxicity findings from PFHxA exposures (HAWC: PFHxA – Human Toxicity Endocrine Effects link (https://hawcprd.epa.gov/summary/visual/100500126/))

Diagram showing the study evaluation for human epidemiologic studies reporting toxicity findings from PFHxA exposures.

#### Animal

Four short-term (28-day), subchronic, and chronic animal studies evaluated potential endocrine effects of PFHxA or PFHxA sodium salt in rats. Most of the outcome-specific study ratings were rated high confidence. Histopathology for Chengelis et al. (2009b) was rated low confidence because of issues related to observational bias, concerns about endpoint sensitivity and specificity, and results presentation. A summary of the studies and the interpretations of confidence in the results for the different outcomes based on the individual study evaluations is presented in Table 3-26, and details are available by clicking the HAWC link (https://hawcprd.epa.gov/summary/visual/100500177/).

Table 3-26 Endocrine endpoints for PFHxA and associated confidence scores from repeated-dose animal toxicity studies

Author (year) | Species, strain (sex) | Exposure design | Exposure route and dose range | Organ weight | Histopathology | Thyroid hormones
NTP (2018) | Rat, Harlan Sprague-Dawley (male and female) | Short term (28 d) | Gavage^a^; Male and female: 0, 62.5, 125, 250, 500, 1,000 mg/kg-d | ++ | ++ | ++
Chengelis et al. (2009b) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | Subchronic (90 d) | Gavage^a^; Male and female: 0, 10, 50, 200 mg/kg-d | ++ | − | NM
Loveless et al. (2009) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | Subchronic (90 d) | Gavage^b^; Male and female: 0, 20, 100, 500 mg/kg-d | ++ | ++ | NM
Klaunig et al. (2015) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | 2-yr cancer bioassay | Gavage^a^; Male: 0, 2.5, 15, 100 mg/kg-d; Female: 0, 5, 30, 200 mg/kg-d | NM | ++ | NM

++ Outcome rating of high confidence; − outcome rating of low confidence; NM, outcome not measured.

a,b Study evaluation for animal toxicological endocrine endpoints reported from studies with male and female rats receiving PFHxA^a^ or PFHxA sodium salt^b^ by gavage. Study evaluation details for all outcomes are available by clicking the HAWC link (https://hawcprd.epa.gov/summary/visual/100500177/).

++ Outcome rating of high confidence; − outcome rating of low confidence; NM, outcome not measured.

##### Thyroid Hormones

A single study evaluated potential PFHxA effects on endocrine function specific to thyroid hormones in rats exposed for 28 days (NTP, 2018). Specifically, males showed statistically significant, dose-dependent decreases in thyroid hormones. These outcomes showed a clear dose-dependent pattern of effect with treated animals showing reductions of 25%–73% or 20%–58% for free or total T4, respectively. Smaller decreases in T3 in males also were observed (18%–29%), although the dose-dependence of this effect was less clear. No treatment-related changes were observed for T3 or T4 in females or for TSH in either sex (NTP, 2018). Results are summarized in Figure 3-18 and Table 3-27.

Figure 3-18 Thyroid hormone measures from the serum of rats exposed by gavage to PFHxA or PFHxA sodium salt (full details available by clicking the HAWC link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-endocrine-effects-er-array/))

Chart of thyroid hormone measures.

Table 3-27 Percent change in thyroid hormone levels following PFHxA exposure in a 28-day oral toxicity study

Study design and reference | Hormone | Dose (mg/kg-d)
Study design and reference | Hormone | 62.5 | 125 | 250 | 500 | 1,000
28-d, female rat (NTP, 2018) | Free T4 | −1 | −4 | 9 | −4 | −19
28-d, male rat (NTP, 2018) | Free T4 | −25^*^ | −38^*^ | −39^*^ | −55^*^ | −73^*^
28-d, female rat (NTP, 2018) | Total T4 | −7 | −11 | −5 | −9 | −19
28-d, male rat (NTP, 2018) | Total T4 | −20^*^ | −31^*^ | −32^*^ | −44^*^ | −58^*^
28-d, female rat (NTP, 2018) | T3 | −1 | −6 | 3 | 14 | −3
28-d, male rat (NTP, 2018) | T3 | −18^*^ | −26^*^ | −15^*^ | −16^*^ | −29^*^
28-d, female rat (NTP, 2018) | TSH | −15 | −8 | −9 | 40 | −9
28-d, male rat (NTP, 2018) | TSH | 9 | 5 | 6 | 9 | −21

* Indicates instances where statistical significance (p < 0.05) compared to controls was reported by study authors.

##### Histopathology

Four studies evaluated histopathological changes in endocrine tissues, including the thyroid, pituitary, and pancreas, in rodents exposed to PFHxA (NTP, 2018; Klaunig et al., 2015; Chengelis et al., 2009b) or PFHxA sodium salt (Loveless et al., 2009). Of these, Loveless et al. (2009) reported thyroid follicular cell hypertrophy in both male and female rats exposed to PFHxA sodium salt for 90 days. The hypertrophy persisted after the exposure ceased, with females showing an increase at the 30-day (but not 90-day) recovery whereas, in males this effect was observed at the 90-day recovery time point. NTP (2018) reported this outcome was not affected by PFHxA following a 28-day exposure at doses as high as 1,000 mg/kg-day. The remaining two studies reported no treatment-related effects on thyroid histopathology at doses as high as 200 mg/kg-d following subchronic (90-day) or chronic (2-year) exposure to PFHxA. Notably, Chengelis et al. (2009b) did not specify what outcomes were evaluated. Therefore, whether thyroid follicular cell hypertrophy was measured is unclear. No other treatment-related histopathological effects were noted in the PFHxA evidence base. Results are summarized in Table 3-28.

Table 3-28 Incidence of thyroid follicular epithelial cell hypertrophy following PFHxA or PFHxA ammonium salt exposures in rats

Sex (Timepoint) | 0 | 2.5 | 5 | 10 | 15 | 20 | 30 | 50 | 62.5 | 100 | 125 | 200 | 250 | 500 | 1000
28-d exposure in rats (NTP, 2018)
Female | 0/10 | | | | | | | | 0/10 | | 0/10 | | 0/10 | 0/10 | 0/10
Male | 0/10 | | | | | | | | 0/10 | | 0/10 | | 0/10 | 0/10 | 0/10
90-d exposure in rats (Loveless et al., 2009)
Female (Exposure, Day 90) | 0/10 | | | | | 0/10 | | | | 0/11 | | | | 4/10^*^
Male (Exposure, Day 90) | 0/10 | | | | | 0/10 | | | | 1/10^*^ | | | | 2/10^*^
Female (Recovery Day 30) | 0/10 | | | | | | | | | | | | | 6/10^*^
Male (Recovery Day 30) | 0/10 | | | | | | | | | | | | | 3/10^*^
Female (Recovery, Day 90) | 0/10 | | | | | 0/10 | | | | 0/9 | | | | 0/10
Male (Recovery, Day 90) | 0/10 | | | | | 0/10 | | | | 0/10 | | | | 2/10^*^
2-yr exposure in rats (Klaunig et al., 2015)
Female | 0/21 | | 0/25 | | | | 0/20 | | | | | 0/14
Male | 0/18 | 0/24 | | | 0/23 | | | | | 0/24

* Indicates instances where statistical significance (p < 0.05) compared to controls was reported by study authors; shaded cells represent doses not included in the individual studies.

##### Organ Weights

Three studies evaluated effects on thyroid and adrenal weights (NTP, 2018; Chengelis et al., 2009b; Loveless et al., 2009). Although no effects on relative thyroid weight were observed at the end of the 90-day exposure period in either subchronic study, Loveless et al. (2009) qualitatively reported a statistically significant increase in relative thyroid weight for female rats at the highest tested dose (500 mg/kg-day) of PFHxA sodium salt at the 30-day recovery. NTP (2018) observed a trend (p < 0.05) for decreased absolute adrenal gland weight in male rats exposed to 500 mg/kg-day. No other treatment-related effects on endocrine organ weights were observed (NTP, 2018; Chengelis et al., 2009b; Loveless et al., 2009).

#### Mechanistic Evidence and Supplemental Information

##### Thyroid Hormone Levels in Zebrafish

(Zhang et al., 2022) evaluated the effects of a 96-hour exposure to PFHxA (0, 0.48, 2.4, and 12 mg/L) on whole body T3 and T4 levels in early-life stage zebrafish. Whole body total T3 showed a statistically significant increase in high dose animals. For T4 there was a significant dose-dependent reduction in at the low and mid dose, but a significant increase at the high dose.

##### Binding with transport proteins and nuclear receptor

Four studies were identified that investigated the ability of PFHxA to bind to two thyroid hormone serum transport proteins, transthyretin (Hamers et al., 2020; Ren et al., 2016; Weiss et al., 2009) and thyroid binding globulin (Ren et al., 2016), as well as the thyroid hormone receptor (Ren et al., 2015). All studies reported that PFHxA has a low binding affinity for transthyretin and the thyroid hormone receptors, and no detectable binding was observed for thyroid binding globulin.

##### Expression of HPT-related genes and proteins

Three studies evaluated the effects of PFHxA exposure on expression of mRNA and proteins related to thyroid function in early life-stage zebrafish (Zhang et al., 2022), embryonic avian neuronal cells (Vongphachan et al., 2011), and rat hepatoma cells (H4IIE). In zebrafish larvae exposed to up to 12 mg/L PFHxA for 96 h, whole body expression was increased for genes related to HPT regulation (crh, trh), thyroid hormone synthesis (tg, nis), transport (ttr), and nuclear receptors (trα, trβ) after PFHxA exposure. The same study also evaluated protein levels of thyroglobulin and transthyretin, which are important for thyroid hormone synthesis and transport, respectively, and reported treatment-related increases.

Two studies reported changes in mRNA expression of genes involved in metabolism of thyroid hormones (Zhang et al., 2022; Vongphachan et al., 2011). Deiodinases convert thyroid hormones to active and inactive forms through outer and/or inner ring deiodination. Differing patterns of expression were observed for deiodinases, with Vongphachan et al. (2011) finding an increase in deiodinase 2 and 3 in primary chicken neuronal cell cultures whereas Zhang et al. (2022) reported decreases in deiodinases 1 and 2 in early lifestage zebrafish. Ugt1ab, which mediates clearance of thyroid hormones from tissues, was decreased in whole body zebrafish larvae.

Naile et al. (2012) evaluated the effect of PFHxA on mRNA expression of genes related to thyroid development in rat hepatoma cells (H4IIE). Cells exposed to 0.1–100 µM for 72 hours showed increases (19.1–29.29-fold) in expression of Hex, which is important for cell differentiation during development of the thyroid. The effect on Pax8, a gene that regulates proliferation and differentiation of cells that produce thyroxine, was less consistent. In general, there was an increase in expression (2.46-, 1.8-, and 3.73-fold for 0.1, 10, and 100 µM, respectively); however, there was a slight (0.92-fold) decrease in the 1 µm treated cells. The study did not report statistical significance of the results and the data are not sufficient for running statistical analyses as reported.

#### Evidence Integration

A single low confidence study provided some evidence of an association between PFHxA exposure and decreased T3 and TSH in humans, although methodological concerns reduce the reliability of these findings. Based on these results, there is indeterminate human evidence of endocrine effects.

Evidence supporting potential endocrine effects of PFHxA exposure is largely based on two high confidence rat studies showing decreases in serum thyroid hormone levels and increased thyroid epithelial cell hypertrophy in rats, but interpretation of these results is complex. The only available animal study that evaluated thyroid hormone levels showed a large magnitude of change in T4 (up to 73% decrease) and T3 (up to 20% decrease) with a clear dose-response for T4 (free and total) following exposure to PFHxA as low as 62.5 mg/kg-day, and these effects were observed only in males (NTP, 2018). A second study found increased incidence of thyroid epithelial cell hypertrophy following a 90-day exposure to PFHxA sodium salt (Loveless et al., 2009). Effects on thyroid hormone levels were also reported in larval zebrafish exposed to PFHxA during early development. Consistent with the available rodent data, whole body T4 levels were decreased, however T3 levels were increased in zebrafish which is the opposite direction of effects observed in the rat studies. The differences in effects on T3 may be explained by differences in the species (mammalian versus non-mammalian), methods (whole body levels versus serum), and lifestage (developing versus adult).

For the histopathological findings, treatment-related changes were reported for both males and females administered 500 mg/kg-day PFHxA sodium salt. The incidence of thyroid hypertrophy was higher in females than in males, although effects in males persisted longer after exposures had ceased. Also, no clear dose-response was found, with effects generally observed only at the highest dose tested. Three other studies evaluated thyroid histopathology but found no effects in either sex following a wide range of PFHxA exposure durations (28 days to 2 years) and doses (up to 1,000 mg/kg-day) (NTP, 2018; Klaunig et al., 2015; Chengelis et al., 2009b). No clear pattern of treatment-related effects was reported for endocrine organ weights.

Although the only available animal study examining thyroid hormones showed strong effects on T4 and T3 after short-term exposure, no effects were observed on TSH. The observed pattern of effects on the thyroid (i.e., decreased total and free T4 without a compensatory increase in TSH) after PFHxA exposure is consistent with thyroid perturbations following exposure to other PFAS, including PFBA (U.S. EPA, 2022b) and PFBS (U.S. EPA, 2021b). Rodents and humans share many similarities in the production, regulation, and functioning of thyroid hormones. Although differences exist, including the timing of in utero thyroid development and hormone turnover rates, rodents are considered a good model for evaluating the potential for thyroid effects in humans (Zoeller et al., 2007). While there is uncertainty in the reliability of the TSH measurements and patterns of TH changes in animals may not translate perfectly to human clinical definitions, the observed decreases in total or free T4 in the absence of increases in TSH are considered biologically relevant to humans (Crofton, 2004; Lau et al., 2003). TSH is an indicator that the thyroid system has been perturbed, but it does not always change when serum T4 is decreased (Hood et al., 1999) and decreases in T4 alongside normal levels of TSH is consistent with the human clinical condition referred to as hypothyroxinemia [see additional discussion in (U.S. EPA, 2018b)]. Adverse neurological outcomes have been demonstrated following decreased T4 levels during the early neonatal period with no changes in T3 or TSH (Crofton, 2004). During pregnancy and early development, even transient perturbations in thyroid function can have permanent impacts on normal growth and neurodevelopment in the offspring. Although currently available evidence on thyroid hormones is limited to effects in males, there is evidence to support effects in females. Changes in thyroid histopathology were observed in both sexes, with a higher incidence in females (Loveless et al., 2009). Given the potential consistency of these findings with those observed for other PFAS, the availability of a single short-term study of thyroid hormones represents a significant data gap for PFHxA. The lack of consistency of the histopathology findings also reduces the strength of the available evidence; however, this variability across studies could be driven by differences in the dose levels examined (i.e., high dose ranged from 100 to 1,000 mg/kg-day) and exposure duration (i.e., short-term, subchronic, and chronic exposures).

While males exhibited a clear dose-dependent reduction in T4 and T3 at doses as low as 62.5 mg/kg-day in males but no effect in females at doses as high as 1000 mg/kg-day. These disparate results may be explained by sex-specific differences in the pharmacokinetics of PFHxA and its effect on induction of metabolizing enzymes. As discussed in Section 3.1.4, some evidence suggests sex-specific differences in the pharmacokinetics of PFHxA, with plasma concentrations measured 2–3 times higher in male rats when compared to females (Chang et al., 2008; Lau et al., 2006; Lau et al., 2004). Additionally, thyroid hormones may be reduced through PPARα activation and induction of microsomal enzyme inducers, such as CAR and PXR (Vansell, 2022). Males are more sensitive to PFHxA-induced PPARa activation (see Section 3.2.1). While these differences might explain why treatment-related effects on thyroid hormones were observed only in male rats, it is unclear why a similar sex-specific pattern was not observed for the reported thyroid histopathological changes observed at similar or higher doses.

Several mechanisms are implicated in the disruption of thyroid homeostasis. At present there is insufficient evidence identify the MOA(s) by which PFHxA induces the observed thyroid effects, but the mechanistic and supplemental information provide provides some support for PFHxA-related effects on thyroid function. PFHxA may affect thyroid hormone metabolism and bind to transport proteins and the nuclear receptor. Two mechanistic studies show effects on mRNA expression of deiodinases, which are important for conversion of thyroid hormones between active and inactive forms (Zhang et al., 2022; Vongphachan et al., 2011) and glucuronidases which are important for excretion. Additionally, there is evidence that some PFAS may alter thyroid function via interaction with thyroid hormone receptors and transport proteins; however, the current data show only weak binding for PFHxA (Hamers et al., 2020; Ren et al., 2016; Ren et al., 2015; Weiss et al., 2009). Based on available data, there is moderate animal evidence of endocrine effects. In the absence of evidence to the contrary, effects in rats are considered relevant to humans.

Overall, the currently available evidence indicates that PFHxA likely causes endocrine effects in humans given sufficient exposure conditions (see Table 3-29).^8^ This conclusion is based on four animal studies generally rated as high confidence that reported treatment-related decreases in thyroid hormone levels and more uncertain evidence of thyroid histopathology after exposure to PFHxA at ≥62.5 mg/kg-day.

Table 3-29 Evidence profile table for endocrine effects

Evidence stream summary and interpretation | | | | | Evidence integration judgment
Evidence from studies of exposed humans | | | | | ⊕⊕⊙; Evidence indicates (likely); Primary basis:; Two animal studies generally rated as high confidence that reported treatment related changes in thyroid hormone levels, thyroid histopathology after exposure to PFHxA at ≥63.5 mg/kg-d.; Human relevance:; Without evidence to the contrary, effects in rats are considered relevant to humans.; Cross-stream coherence:; N/A (human evidence indeterminate).; Susceptible populations and lifestages:; No evidence to inform; Other inferences:; Some mechanistic data and supplemental information were identified on this health effect were identified that provide additional support for potential PFHxA mediated endocrine effects but are insufficient to inform a potential MOA. Notably, the pattern of the limited human and animal findings for PFHxA are consistent with hypothyroxinemia seen for other PFAS
Studies and confidence | Factors that increase certainty | Factors that decrease certainty | Summary and key findings | Evidence stream judgment
Thyroid Hormones; 1 low (https://hawc.epa.gov/summary/visual/assessment/100500070/pfhxa-human-study-evaluation-endocrine-effects/) confidence study | - No factors noted | - Lack of coherence across related thyroid hormone measures; - Low confidence study | - Inverse associations between free T3 and TSH and PFHxA in a single low confidence study | ⊙⊙⊙; Indeterminate
Evidence from animal studies
Studies and confidence | Factors that increase certainty | Factors that decrease certainty | Summary and key findings | Evidence stream judgment
Thyroid Hormones (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-endocrine-effects-er-array/); 1 high (https://hawcprd.epa.gov/summary/visual/100500177/) confidence study in adult rats:; - 28-d | - High confidence study.; - Dose response gradient observed for free and total T4; - Large effect magnitude; up to 73% | - No factors noted | - Decreased T4 (free and total) and T3 observed in males only at ≥62.5 mg/kg-d | ⊕⊕⊙; Moderate; Some evidence of thyroid effects based on hormone and histopathological changes in two rat studies. Thyroid-related effects in rodents are supported by mechanistic and supplemental information showing changes in thyroid hormone levels in zebrafish larvae, weak binding to thyroid transport proteins/recepto r, and changes in thyroid related mRNA/protein expression.
Histopathology; 3 high (https://hawcprd.epa.gov/summary/visual/100500177/) confidence studies in adult rats:; - 28-d; - 90-d; - 2-yr; 1 low (https://hawcprd.epa.gov/summary/visual/100500177/) confidence study in adult rats:; - 90-d | - High confidence studies | - Unexplained inconsistency across studies | - Increased incidence of thyroid epithelial cell hypertrophy at ≥100 mg/kg-d for 90 d; persisted up to 90 d after exposure; - No effects observed in 28 d study at up to 1,000 mg/kg-d
Organ Weight; High confidence: 3 high (https://hawcprd.epa.gov/summary/visual/100500177/) confidence studies in adult rats:; - 28-d; - 90-d (2 studies) | - High confidence studies | - Unexplained inconsistency across studies | - Relative thyroid weights were increased only in females 30 d after exposure; - Right adrenal weights decreased but no other adrenal effects were reported
Mechanistic evidence and supplemental information
Biological events or pathways | Key findings, interpretation, and limitations | | | Evidence stream summary
Thyroid Hormones | Key findings and interpretation:; - Altered whole body thyroid hormone levels (↑T3, ↓T4) in zebrafish larvae; - Effects T3 shows opposite direction of effect of what was observed in both rodents and humans; Limitations: Small evidence base with some inconsistencies in the pattern of effect observed in human and rodent data | | | Some support for potential effects of PFHxA on thyroid function.
Receptor/Transport Protein Binding | Key findings and interpretation:; - Low binding potency for transthyretin and thyroid hormone receptor; - No observed binding to thyroid binding globulin; Limitations: Small evidence base showing weak effect. | | | Some support for potential effects of PFHxA on thyroid function.
mRNA/Protein Expression | Key findings and interpretation:; - Altered expression of several thyroid-related mRNA and proteins observed in vivo (larval zebrafish) and in vitro (primary chicken neuronal cells; rat hepatoma, H4IIE); - Potential targets included pathways relevant to all aspects of thyroid regulation including, synthesis, release, transport, and metabolism of thyroid hormones as well as regulation of thyroid development, but in general each target evaluated by a single study; - Lack of consistency of effect in two studies that evaluated mRNA expression of deiodinase 2; Limitations: Small evidence base lacking consistency across different studies (when available) for deiodinase 2 | | | Some support for potential effects of PFHxA on thyroid function.

### 3.2.6 Male Reproductive Effects

#### Human

##### Sperm Parameters

One low confidence study (Song et al., 2018) examined the association between PFHxA exposure and semen parameters and reported no decrease in concentration or motility with higher levels of PFHxA in serum (see Figure 3-19). A significant negative correlation between PFHxA levels in semen and sperm motility was found in this study (correlation coefficient = −0.35, p < 0.01), but analytical measurement of PFAS in semen is less established than in blood and the relevance to exposure is unclear. Still, exposure levels in the study based on serum measurements were high (median: 29 ng/mL, 5th–95th percentile: 11–70 ng/mL), so the study had reasonable sensitivity to detect an effect.

##### Reproductive Hormones

A single study rated low confidence due to low sensitivity and high potential for confounding (see Figure 3-19) found some support for associations between PFHxA and reproductive hormones in a population of adolescent (13–15 years old) males in Taiwan (Zhou et al., 2016). Overall, authors reported no significant associations between PFHxA and serum testosterone and estradiol; however, when the data were stratified by sex, a significant negative association between testosterone and PFHxA exposure level (β = −0.31, 95% CI: −0.59, −0.02) was found in boys. Based on serum measurements, the exposure levels in this study were low and the range narrow (median: 0.2 ng/mL, IQR 0.1–0.3 ng/mL), which might have reduced study sensitivity. The presence of an association despite reduced sensitivity could be due to either high potency of the exposure to cause these effects or potential confounding by other correlated PFAS, including PFOS, PFDA, and PFNA.

Figure 3-19 Study evaluation for human epidemiological studies reporting male reproductive findings from PFHxA exposures (HAWC: PFHxA – Human Toxicity Male Reproductive Effects link (https://hawcprd.epa.gov/summary/visual/100500127/))

Diagram of the study evaluation for human epidemiological studies / male reproductive findings.

#### Animal

Several short-term (28-day), subchronic, and chronic animal studies evaluated sperm parameters, reproductive organ weights, and other reproductive male outcomes in rats receiving oral exposures of PFHxA and PFHxA sodium salt. Most outcome-specific study ratings were rated high confidence; however, some specific concerns were identified that resulted in low confidence ratings. Although generally a well-conducted study, NTP (2018) was rated low confidence for sperm parameters due to issues related to exposure duration and concerns for potential insensitivity. Histopathological results for Chengelis et al. (2009b) were rated low confidence because of issues related to observational bias, concerns about endpoint sensitivity and specificity, and results presentation. The results of the outcome-specific study evaluations are presented in Table 3-30, and details are available by clicking the HAWC link (https://hawcprd.epa.gov/summary/visual/100500177/).

Table 3-30 Study design, exposure characteristics, and individual outcome ratings

Study | Species, strain (sex) | Exposure design | Exposure route and dose | Sperm parameters | Organ weight | Histopathology | Hormone levels | Reproductive system development
NTP (2018) | Rat, Harlan Sprague-Dawley (male and female) | Short term; (28 d) | Gavage^a^; Male and female: 0, 62.5, 125, 250, 500, 1,000 mg/kg-d | − | ++ | ++ | ++ | NM
Chengelis et al. (2009b) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | Subchronic; (90 d) | Gavage^a^; Male and female: 0, 10, 50, 200 mg/kg-d | NM | ++ | − | NM | NM
Loveless et al. (2009) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | Subchronic (90 d); One-generation reproductive: P_0_ females dosed 70 d prior to cohabitation, through gestation and lactation (126 d); P_0_ males dosed for 110 d; Developmental: Gestation Days 6–20 | Gavage^b^; Male and female: 0, 20, 100, 500 mg/kg-d | ++ | ++ | ++ | NM | ++
Klaunig et al. (2015) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | 2-yr cancer bioassay | Gavage^a^; Male: 0, 2.5, 15, 100 mg/kg-d; Female: 0, 5, 30, 200 mg/kg-d | NM | NM | ++ | ++ | NM
Iwai and Hoberman (2014) ^c^ | Mouse, Crl:CD1(ICR); Charles River Laboratories, Inc. | Gestation Days 6–18 | Gavage^d^; Phase 1: 0, 100, 350, 500 mg/kg-d; Phase 2: 0, 7, 35, 175 mg/kg-d | NM | NM | NM | NM | ++

++ Outcome rating of high confidence; − outcome rating of low confidence; NM, outcome not measured.

a,b,d Study evaluation for animal toxicological endpoints reported from male reproductive studies with rats receiving PFHxA,^a^ PFHxA sodium salt,^b^ or PFHxA ammonium salt^d^ by gavage. Study evaluation details for all outcomes are available by clicking the HAWC link (https://hawcprd.epa.gov/summary/visual/100500177/).

c Phase 1 was a range-finding study used to determine the appropriate dose range for identification of a NOAEL in Phase 2.

##### Sperm Parameters

Evidence from a 28-day (NTP, 2018) and one-generation reproductive study (Loveless et al., 2009) included sperm parameters useful in evaluating potential male reproductive effects (see Figure 3-20). In male rats receiving PFHxA daily by gavage for 28 days, a trend (p < 0.05) for decreased sperm count in the cauda epididymis was identified with a significant (25% change from control) decrease in the 1,000 mg/kg-day dose group. Animals in this dose group showed a significant decrease in body weight (13% change from control) at the end of the study but no other overt toxicity was indicated (e.g., mortalities or significant clinical observations) (NTP, 2018). Notably, these effects were observed despite concerns about sensitivity due to the short exposure duration of the study by NTP (2018) which does not encompass a full 6-week spermatogenic cycle in rats. In the one-generation reproductive study, Loveless et al. (2009) found no treatment-related effects for sperm parameters following a 10-week premating exposure in male rats to PFHxA sodium salt at doses up to 500 mg/kg-day. Results are summarized in Figure 3-20.

Figure 3-20 Male reproductive effects on sperm parameters in male rats exposed to PFHxA or sodium salt for 28 or 90 days (HAWC: PFHxA – Animal Toxicity Male Reproductive Effects link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-male-reproductive-effects-/))

Chart of male reproductive effects based on PFHxA exposure.

##### Reproductive Organ Weights

Reproductive studies commonly report both absolute and relative organ weights; however, for the testes, absolute weights are considered most informative for hazard evaluation (Bailey et al., 2004). Three studies (28- or 90-day exposure durations) reported data on the effects of PFHxA or PFHxA sodium salt exposure on male reproductive organ weights (i.e., testes, epididymis) in rats (see Figure 3-21) (NTP, 2018; Chengelis et al., 2009b; Loveless et al., 2009). Two studies reported a modest, but statistically significant (p < 0.05; 13%–16% change from control), increase in relative, but not absolute, testis weight in rats exposed to 1,000 mg/kg-day for 28 days (NTP, 2018) or 500 mg/kg-day for 90 days (Loveless et al., 2009). No treatment-related effects on male reproductive organ weights were reported by Chengelis et al. (2009b).

Figure 3-21 Male reproductive effects on epididymis and testis weight in rats exposed to PFHxA or PFHxA sodium salt (HAWC: PFHxA – Animal Toxicity Male Reproductive Effects link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-reproductive-effects-animal-toxicology/))

Chart showing male reproductive effects on epididymis and testis weight in exposed rats.

##### Reproductive Hormones

Two studies measured hormone levels (i.e., testosterone, estradiol, and luteinizing hormone) following exposure to PFHxA (NTP, 2018; Klaunig et al., 2015). Klaunig et al. (2015) reported a small, transient decrease in testosterone and luteinizing hormone in males at the 26-week time point. Effects were not dose dependent and were not significantly different from controls at doses up to 100 mg/kg-day PFHxA. This pattern was not observed at the 52-week time point. A short-term study found no effects on testosterone following exposure of up to 1,000 mg/kg-day for 28 days (NTP, 2018). Klaunig et al. (2015) also measured estradiol but found no treatment-related changes.

##### Histopathology

Four studies evaluated effects of PFHxA or PFHxA sodium salt on histopathology of the testes and epididymites and reported no treatment-related changes (NTP, 2018; Klaunig et al., 2015; Chengelis et al., 2009b; Loveless et al., 2009). One study was rated low confidence for this outcome (Chengelis et al., 2009b).

##### Male Reproductive System Development

Two studies examined outcomes related to male reproductive system development following developmental exposure to PFHxA ammonium or sodium salts (Iwai and Hoberman, 2014; Loveless et al., 2009). No treatment-related effects were reported on the age at preputial separation, a marker of puberty onset.

##### Evidence Integration

The available evidence informing the potential for an effect of PFHxA exposure on male reproduction in humans was limited to two low confidence studies that provided some indication of an association between PFHxA exposure and sperm motility (Song et al., 2018) and reproductive hormone levels (Zhou et al., 2016). These results are difficult to interpret, however, based on the availability of a single study for each outcome and the high risk for bias in these evaluations. Based on these results, there is indeterminate human evidence of male reproductive effects.

In animals, the evidence supporting potential effects of PFHxA exposure on male reproduction was primarily limited to decreased sperm count (NTP, 2018) and increased relative testis weights (NTP, 2018; Loveless et al., 2009) at the highest tested doses in these studies (1,000 and 500 mg/kg-day, respectively). Decreased sperm count reported by NTP (2018) was considered low confidence due to the 28-day exposure duration and concerns that such short exposures would not capture the full spermatogenic cycle. Although finding effects in the presence of an insensitive exposure duration could indicate a sensitive window for chemical-specific perturbations, similar results were not observed in a high confidence subchronic study performed in the same rat strain (Loveless et al., 2009), albeit the highest tested dose was 500 as compared to 1,000 mg/kg-day in the short-term study. In addition, evidence of overt toxicity (i.e., 13% reduction in terminal body weight relative to controls) was found in the male rats dosed 1,000 mg/kg-day in the NTP (2018) study.

Two studies reported increased relative testis weight; however, the preferred metric of absolute testis weight did not change in either study and no changes in organ weight were observed in a second subchronic study (Chengelis et al., 2009b). Reproductive hormone (i.e., testosterone and luteinizing hormone) levels were reduced in the only chronic study; however, the effect was small in magnitude, was not dose-dependent, and was observed only at the 26-week time point (Klaunig et al., 2015). Similar results on testosterone were not reported in the short-term high confidence study (NTP, 2018). No other coherent findings (i.e., reproductive histopathology and male reproductive system development) supporting reproductive toxicity were identified in the animal evidence base. Based on these results there is indeterminate animal evidence of male reproductive effects.

Overall, the currently available evidence is inadequate to assess whether PFHxA might cause male reproductive effects in humans (see Table 3-31).

Table 3-31 Evidence profile table for male reproductive effects

Evidence stream summary and interpretation | | | | | Evidence integration summary judgment
Evidence from studies of exposed humans | | | | | ⊙⊙⊙; Evidence inadequate; Primary Basis:; Evidence is low confidence or largely null; Human relevance:; N/A (indeterminate animal evidence); Cross stream coherence:; N/A (human evidence indeterminate); Susceptible population and lifestages:; No evidence to inform
Studies and confidence | Factors that increase certainty | Factors that decrease certainty | Summary and key findings | Evidence stream judgment
Sperm Parameters; 1 low (https://hawc.epa.gov/summary/visual/assessment/100500070/pfhxa-human-study-evaluation-male-reproductive-eff/) confidence study | - No factors noted | - Low confidence study. | - Association between PFHxA levels in semen and decreased sperm motility | ⊙⊙⊙; Indeterminate
Reproductive Hormones; 1 low (https://hawc.epa.gov/summary/visual/assessment/100500070/pfhxa-human-study-evaluation-male-reproductive-eff/) confidence study | - No factors noted | - Low confidence study | - Significant inverse association between PFHxA exposure and testosterone despite poor sensitivity | ⊙⊙⊙; Indeterminate
Evidence from animal studies
Studies and confidence | Factors that increase certainty | Factors that decrease certainty | Summary and key findings | ⊙⊙⊙; Indeterminate; The data are largely null. Some evidence of reproductive effects but interpretation limited by unexplained inconsistency at effects observed only at the high dose that elicited high overt toxicity (i.e., 13% decrease in body weight).
Sperm Parameters (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-male-reproductive-effects-/); 1 high (https://hawc.epa.gov/summary/visual/assessment/100500070/animal-toxicology-study-evaluation/) confidence study in adult rats:; - 90-d; 1 low (https://hawc.epa.gov/summary/visual/assessment/100500070/animal-toxicology-study-evaluation/) confidence in adult rats; - 28-d | - No factors noted | - Unexplained inconsistency across studies | - Decreased sperm count in the cauda epididymis at 1,000 mg/kg-d
Organ Weights (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-reproductive-effects-animal-toxicology/); 3 high (https://hawc.epa.gov/summary/visual/assessment/100500070/animal-toxicology-study-evaluation/) confidence studies in adult rats:; - 28-d; - 90-d (2 studies) | - High confidence studies; - Dose response with longer exposure duration | - No factors noted | - Increased relative testis weight at ≥500 mg/kg-d; no change in absolute testis weights (preferred metric)
Reproductive Hormones; 2 high (https://hawc.epa.gov/summary/visual/assessment/100500070/animal-toxicology-study-evaluation/) confidence studies in adult rats:; - 28-d; - 2-yr | - High confidence studies | - No factors noted | - Transient decrease of small magnitude in luteinizing hormone and testosterone
Histopathology and Male Reproductive System Development; 4 high (https://hawc.epa.gov/summary/visual/assessment/100500070/animal-toxicology-study-evaluation/) confidence studies in rats and mice:; - 28-d (rat); - 90-d (rat); - GD 6–18 (mouse); - 2-yr (rat); 1 low (https://hawc.epa.gov/summary/visual/assessment/100500070/animal-toxicology-study-evaluation/) confidence study in adult rats:; - 90-d | - High confidence studies | - No factors noted | - No treatment-related effects reported at ≤1,000 mg/kg-d
Mechanistic evidence and supplemental information
Biological events of pathways | Biological events of pathways | Biological events of pathways | | Biological events of pathways
- No studies identified

### 3.2.7 Female Reproductive Effects

#### Human

##### Reproductive Hormones

A single low confidence study (see Figure 3-22) evaluated associations between PFHxA and reproductive hormones in a population of Taiwanese adolescents (13–15 years old) (Zhou et al., 2016). Overall, the authors reported nonsignificant inverse associations between PFHxA and serum testosterone and estradiol in females when the data were stratified by sex. Exposure levels to PFHxA were low, which might have reduced study sensitivity, as described above in Section 3.2.6. Male Reproductive Effects.

Figure 3-22 Study evaluation for human epidemiological studies reporting female reproductive findings from PFHxA exposures (HAWC: PFHxA – Human Toxicity Female Reproductive link (https://hawcprd.epa.gov/summary/visual/100500128/))

Diagram of the study evaluation.

#### Animal

Five animal studies evaluated outcomes related to female reproduction in rats and mice receiving PFHxA via gavage, PFHxA sodium salt, or PFHxA ammonium salt. Study designs included short-term (28-day), subchronic (90-day), and chronic (2-year) one-generation reproductive and developmental exposures. In general, the outcome-specific study ratings were high confidence. One study was rated low confidence for histopathology due to concerns about observational bias, endpoint sensitivity and specificity, and results presentation (Chengelis et al., 2009b). The results of study evaluation for female reproductive outcomes are presented in Table 3-32 and details are available by clicking the HAWC link (https://hawcprd.epa.gov/summary/visual/100500177/).

Table 3-32 Study design characteristics

Study | Species, strain (sex) | Exposure design | Exposure route and dose | Fertility and pregnancy | Organ weight | Histopathology | Reproductive hormones | Reproductive system development
NTP (2018) | Rat, Harlan Sprague-Dawley (male and female) | Short term; (28 d) | Gavage^a^; Male and female: 0, 62.5, 125, 250, 500, 1,000 mg/kg-d | ++ | ++ | ++ | ++ | NM
Chengelis et al. (2009b) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | Subchronic; (90 d) | Gavage^a^; Male and female: 0, 10, 50, 200 mg/kg-d | NM | ++ | − | NM | NM
Loveless et al. (2009) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | Subchronic (90 d); One-generation reproductive: P_0_ females dosed 70 d prior to cohabitation, through gestation and lactation (126 d); P_0_ males dosed for 110 d; Developmental: Gestation Days 6–20 | Gavage^b^; Male and female: 0, 20, 100, 500 mg/kg-d | ++ | ++ | ++ | NM | ++
Klaunig et al. (2015) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | 2-yr cancer bioassay | Gavage^a^; Male: 0, 2.5, 15, 100 mg/kg-d; Female: 0, 5, 30, 200 mg/kg-d | NM | NM | ++ | ++ | NM
Iwai and Hoberman (2014) ^c^ | Mouse, Crl: CD1(ICR) () (male and female) | Developmental: Gestation Days 6–18 | Gavage^d^; Phase 1: 0, 100, 350, 500 mg/kg-d; Phase 2: 0, 7, 35, 175 mg/kg-d | ++ | NM | ++ | NM | ++

++ Outcome rating of high confidence; − outcome rating of low confidence; NM, outcome not measured.

a,b,d Study evaluation for animal toxicological endpoints reported from female reproductive studies with rats receiving PFHxA,^a^ PFHxA sodium salt,^b^ or PFHxA ammonium salt^d^ by gavage. Study evaluation details for all outcomes are available by clicking the HAWC link (https://hawcprd.epa.gov/summary/visual/100500177/).

c Phase 1 was a range-finding study used to determine the appropriate dose range for identification of a NOAEL in Phase 2.

++ Outcome rating of high confidence; − outcome rating of low confidence; NM, outcome not measured.

##### Fertility and Pregnancy Outcomes

Three studies published in two reports evaluated outcomes related to fertility and pregnancy following exposure by gavage with PFHxA or PFHxA salts in rats or mice (Iwai and Hoberman, 2014; Loveless et al., 2009). Some effects on maternal body weight change (i.e., gain or loss) were noted. In both the developmental and one-generation reproductive rat studies (Loveless et al., 2009), statistically significant reductions in maternal body weight change were observed during gestation in the high dose group (500 mg/kg-day). In the developmental study (Loveless et al., 2009), there was a statistically significant decrease in total maternal body weight gain (19% relative to control) and when correcting for gravid uterine weight (26% relative to control) from GD 6–21 in the 500 mg/kg-day dose group. In the one-generation reproductive study, similar effects were observed but were limited to early gestation (Loveless et al., 2009). From GD 0–7, body weight gain in dams exposed to 500 mg/kg-day was reduced by 31% relative to controls. There was no treatment-related effect on maternal weight gain over the entire gestational period (GD 0–21) and the high dose (500 mg/kg-day) showed a statistically significant increase in body weight change relative to controls during lactation (PND 0–21) (Loveless et al., 2009). No changes in maternal body weight gain were identified in mice (Iwai and Hoberman, 2014).

Only one of the three available studies reported effects on absolute maternal body weight. In the developmental rat study, dams exposed to 500 mg/kg-day (GD 6–20) showed a statistically significant decrease in terminal body weight (7% relative to control) (Loveless et al., 2009). Deficits remained when correcting for gravid uterine weight (5% relative to control), indicating the effects on body weight were driven by maternal body weight rather than reductions in fetal body weight or number of fetuses. However, this level of change may not be biologically significant (U.S. EPA, 1991). There was no effect on absolute maternal body weight in the one-generation reproductive rat or mouse study (Iwai and Hoberman, 2014; Loveless et al., 2009). These results are presented in Figure 3-23.

No treatment-related effects on mating, pregnancy incidence, gestation length, number of implantations, or litter size were reported in either study that evaluated these outcomes (Iwai and Hoberman, 2014; Loveless et al., 2009). Estrous cyclicity in rats exposed as adults or during gestation was also unaffected in two studies (NTP, 2018; Loveless et al., 2009).

Figure 3-23 Effects on body weight in female rats and mice exposed to PFHxA or PFHxA ammonium salt in reproductive studies (HAWC: PFHxA – Animal Toxicity Female Reproductive Supporting Table (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/PFHxA-Animal-Toxicology-Female-Reproductive-bw/))

Chart showing the effects on body weight.

##### Histopathology

Four studies evaluated effects on histopathology of reproductive organs (i.e., uterus and ovaries) in rodents following exposure to PFHxA (NTP, 2018; Klaunig et al., 2015; Chengelis et al., 2009b) or PFHxA sodium salt (Loveless et al., 2009). Only NTP (2018) reported an effect of exposure, with females showing a statistically significant increase in the incidence of bilateral uterine horn dilation in all but the vehicle controls and highest dose group (see Figure 3-24). Whereas the control and high-dose group had 10 animals per group, however, groups showing a statistically significant increase had only 1–3 animals per group, complicating interpretation of these findings. The total incidence ranges from 1 to 3 animals/treatment group, regardless of sample size or PFHxA dose (see Figure 3-24). The biological significance of these results is unclear. Uterine horn dilation can indicate an estrogenic effect, but no coherent changes in serum estradiol or estrous cyclicity were observed in this study. Similarly, no other treatment-related effects on female reproductive histopathology were reported (NTP, 2018; Klaunig et al., 2015; Chengelis et al., 2009b; Loveless et al., 2009).

Figure 3-24 Female reproductive effects on uterine horn dilation in rats exposed to PFHxA for 28 days (HAWC: PFHxA – Animal Toxicity Female Reproductive link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicologyfemale-reproductive-histopa/))

Bar chart showing the female reproductive effects on exposed rats.

##### Organ Weights

Three studies evaluated effects of PFHxA exposure on uterine and ovarian weights (NTP, 2018; Chengelis et al., 2009b; Loveless et al., 2009). Authors reported no treatment-related effects for these outcomes.

##### Reproductive Hormones

Two studies measured effects of PFHxA or PFHxA ammonium salt on testosterone (NTP, 2018; Klaunig et al., 2015), estradiol, and luteinizing hormone (Klaunig et al., 2015). No treatment-related effects were reported in either study.

##### Female Reproductive System Development

Two studies evaluated the potential for reproductive development effects following developmental exposure to PFHxA ammonium or sodium salts. Iwai and Hoberman (2014) and Loveless et al. (2009) found no effects on age at vaginal opening, a measure of puberty onset.

#### Evidence Integration

A single low confidence human study reported a weak inverse association between PFHxA exposure measures and serum levels of reproductive hormone levels in adolescents (Zhou et al., 2016). Based on these results, there is indeterminate human evidence of female reproductive effects.

In animals, evidence supporting effects of PFHxA exposure female reproduction was largely limited to effects on maternal weight gain during gestation in rats exposed to 500 mg/kg-day (Loveless et al., 2009). These effects corresponded with a small but statistically significant absolute body weight in the high confidence developmental rat study only (Loveless et al., 2009), however the level of the decrease (5%–7%) may not be biologically significant. There were no effects on maternal weight or weight gain in the in the mouse study. The reported effects on uterine horn dilation appears to be influenced by differences in sample sizes, as the total incidence of the finding is similar across controls and all dosing groups. Furthermore, this finding is generally associated with estrogenic effects, but no coherent changes were observed that would be indicative of estrogenic changes in females. No treatment-related changes were reported for other female reproductive outcomes (NTP, 2018; Klaunig et al., 2015; Iwai and Hoberman, 2014; Chengelis et al., 2009b; Loveless et al., 2009). Based on these results, there is indeterminate animal evidence of female reproductive effects.

Overall, the currently available evidence is inadequate to assess whether PFHxA might cause female reproductive effects in humans (see Table 3-33).

Table 3-33 Evidence profile table for female reproductive effects

Evidence stream summary and interpretation | | | | | Evidence integration summary judgment
Evidence from studies of exposed humans | | | | | ⊙⊙⊙; Evidence inadequate
Studies and confidence | Factors that increase strength | Factors that decrease certainty | Summary and key findings | Evidence stream judgment | ⊙⊙⊙; Evidence inadequate
Reproductive Hormones; 1 low (https://hawc.epa.gov/summary/visual/assessment/100500070/pfhxa-human-study-evaluation-female-reproductive-e/) confidence study | - No factors noted | - Low confidence study | - Nonsignificant inverse association between PFHxA exposure and testosterone and estradiol | ⊙⊙⊙; Indeterminate | ⊙⊙⊙; Evidence inadequate
Evidence from animal studies
Studies and confidence | Factors that increase strength | Factors that decrease certainty | Summary and key findings | Evidence stream judgment | Primary Basis:; Evidence is low confidence or largely null.; Human relevance:; - N/A (human and animal evidence both indeterminate); Cross stream coherence:; - N/A (human and animal evidence both indeterminate); Susceptible populations:; - None identified
Fertility and Pregnancy Outcomes (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/PFHxA-Animal-Toxicology-Female-Reproductive-bw/); 3 high (https://hawcprd.epa.gov/summary/visual/100500177/) confidence studies in rats and mice:; - 28-d (rat); - 90-d (rat); - GD 6–18 (mouse) | - High confidence studies | - Unexplained inconsistency across studies | - Decreases in maternal weight gain during gestation in rats exposed to 500 mg/kg-d | ⊙⊙⊙; Indeterminate; The animal evidence is largely null. Some evidence of female reproductive effects but body weight effects lacked consistency across studies. Histopathology effects were not dosedependent and lacked coherent evidence to support the biological significance of the findings
Histopathology (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicologyfemale-reproductive-histopa/); 4 high (https://hawcprd.epa.gov/summary/visual/100500177/) confidence studies in rats and mice:; - 28-d (rat); - 90-d (rat); - 2-yr (rat); - GD 6–18 (mouse); 1 low (https://hawcprd.epa.gov/summary/visual/100500177/) confidence study in adult rats:; - 90-d | - High confidence studies | - Unexplained inconsistency across studies; - Lack of expected coherence with other estrogen related outcomes | - Increase in bilateral uterus dilation reported for all groups except the highest dose
Organ Weights, Reproductive Hormones, Reproductive System Development; 6 high (https://hawcprd.epa.gov/summary/visual/100500177/) confidence studies in rats and mice:; - 28-d (rat); - 90-d (rat, 2 studies); - 2-yr (rat); - GD 6–18 (mouse); - GD 6–20 (rat) | - High confidence studies | - No factors noted | - No treatment-related effects were reported at ≤1,000 mg/kg-d
Mechanistic evidence and supplemental information
Biological events of pathways | Biological events of pathways | Biological events of pathways | | Biological events of pathways
- No studies Identified

### 3.2.8 Immune Effects

#### Human

##### Asthma, Immune Markers, and Potentially Related Respiratory Outcomes

One medium confidence case-control study in Taiwan of asthma was reported in three publications (Qin et al., 2017; Zhou et al., 2017; Dong et al., 2013). Dong et al. (2013) includes results from all three studies that examined the potential association between PFHxA exposure and asthma incidence or severity, control of asthma symptoms and related immune markers (see Figure 3-25). The study also measured pulmonary function. The only finding of note was a nonmonotonic positive association between incident asthma (i.e., diagnosis in the previous year) and PFHxA exposure (odds ratio [95% CI] for Q2: 1.2 [0.7, 2.1], Q3: 0.9 [0.5, 1.6], Q4: 1.6 [0.9, 2.9]) that was not statistically significant. No clear association was found with asthma severity or control of asthma symptoms (Dong et al., 2013), pulmonary function measured with spirometry (Qin et al., 2017), or immune markers (Dong et al., 2013) among children with asthma. The exposure levels in this study were low and contrast narrow (median [IQR]: 0.2 ng/mL [0.1−0.3 ng/mL]), which may have reduced study sensitivity.

Figure 3-25 Study evaluation for human epidemiological studies reporting findings from PFHxA exposures (HAWC: PFHxA – Human Toxicity Immune Effects link (https://hawcprd.epa.gov/summary/visual/100500129/))

The evaluation of Dong et al. (2013) encompasses all publications related to this study.

Diagram showing the results of the study evaluation.

#### Animal

Several animal studies, including short-term (28-day), subchronic, reproductive, and designs, evaluated toxicological findings of immune effects in rats receiving oral exposures of PFHxA and PFHxA sodium salt. Most of the outcome-specific study ratings were considered high or medium confidence; however, some specific concerns were identified that resulted in a low confidence rating. Histopathology for Chengelis et al. (2009b) was rated low confidence because of issues related to observational bias, concerns about endpoint sensitivity and specificity, and results presentation. The results of the outcome-specific study evaluations are presented in Table 3-34 and details are available by clicking the HAWC link (https://hawcprd.epa.gov/summary/visual/100500177/).

Table 3-34 Study design characteristics and individual outcome ratings for immune endpoints

Study | Species, strain (sex) | Exposure design | Exposure route and dose | Organ weight | Histopathology | Immune cell counts
NTP (2018) | Rat, Harlan Sprague-Dawley (male and female) | Short term; (28 d) | Gavage^a^; Male and female: 0, 62.5, 125, 250, 500, 1,000 mg/kg-d | ++ | ++ | ++
Kirkpatrick (2005a) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | Reproductive: P_0_ animals dosed 14 d prior to mating through end of mating period (male) or PND 4 (female) | Gavage^a^; Male and female: 50, 150 and 300/450^c^ mg/kg/d | + | + | +
Chengelis et al. (2009b) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | Subchronic; (90 d) | Gavage^a^; Male and female: 0, 10, 50, 200 mg/kg-d | ++ | − | ++
Loveless et al. (2009) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | Subchronic (90 d) | Gavage^b^; Male and female: 0, 20, 100, 500 mg/kg-d | ++ | ++ | ++
Klaunig et al. (2015) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | 2-yr cancer bioassay | Gavage^a^; Male: 0, 2.5, 15, 100 mg/kg-d; Female: 0, 5, 30, 200 mg/kg-d | NM | ++ | ++

++ Outcome rating of high confidence; + outcome rating of medium confidence; − outcome rating of low confidence; NM, outcome not measured.

a,b Study evaluation for animal toxicological immune endpoints reported from studies with male and female rats receiving PFHxA^a^ or PFHxA sodium salt^b^ by gavage. Study evaluation details for all outcomes are available by clicking the HAWC link (https://hawcprd.epa.gov/summary/visual/100500177/).

c Due to high toxicity at the 450 mg/kg-d exposed animals, dosage was reduced to 300 mg/kg-d on exposure day 4.

##### Organ Weights

Four studies evaluated effects on spleen and thymus weights in response to PFHxA (NTP, 2018; Chengelis et al., 2009b; Kirkpatrick, 2005a) or PFHxA sodium salt (Loveless et al., 2009) exposure.

The available evidence identified, in general, decreased absolute or relative thymus weights. Two studies reported statistically significant decreases in absolute thymus weights in males exposed to 500 mg/kg-day PFHxA sodium salt for 90 days (Loveless et al., 2009) or 450/300 mg/kg-day in reproductive study (Kirkpatrick, 2005a). Similarly, downward trends in both relative and absolute thymus weights thymus were reported in males and females receiving PFHxA in the short term (NTP, 2018). A single study qualitatively reported no treatment-related effects on thymus weights (Chengelis et al., 2009b).

Spleen weights did not show a clear pattern of effect across studies. In the short-term study, a trend of increased weights in males and females receiving PFHxA (NTP, 2018) was observed, whereas spleen weights were decreased in males receiving PFHxA sodium salt in the 90-day study by Loveless et al. (2009). Both Chengelis et al. (2009b) and Kirkpatrick (2005a) reported no treatment-related effects on spleen after exposure to ≤450 mg/kg-day PFHxA for up to 90 days. Results are summarized in Figure 3-26.

Figure 3-26 Immune organ weights in rats exposed by gavage to PFHxA or PFHxA sodium salt (HAWC: PFHxA – Animal Toxicity Immune Effects link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-immune-effects-organ-weigh/))

Chart displaying organ weights in rats.

##### Histopathology

Five studies examined spleen, thymus, lymph nodes, or bone marrow for histopathological changes (NTP, 2018; Klaunig et al., 2015; Chengelis et al., 2009b; Loveless et al., 2009; Kirkpatrick, 2005a). Some evidence of effects on immune related histopathology was reported by NTP (2018) reported an increased incidence of extramedullary hematopoiesis in the spleens of males and females at 1,000 mg/kg-day after a 28-day exposure. Minimal to mild extramedullary hematopoiesis also was found in the spleens of male rats receiving 500 mg/kg-day PFHxA sodium salt (Loveless et al., 2009). This effect was coincident with erythroid hyperplasia of the bone marrow of males and females and might be related to the effects on red blood cells (discussed in “Hemostasis” of Section 3.2.4) rather than an immune-specific effect. These changes did not persist after the 30-day recovery and specific incidence data were not reported (Loveless et al., 2009). A reproductive study in rats reported increased incidence of histopathologic changes in the spleen, thymus, and lymph nodes in the high dose group (450/300 mg/kg-day). Notably, these findings were limited to unscheduled deaths (i.e., found dead or euthanized in extremis) in animals showing signs of overt toxicity, therefore, these results may not reflect an immune-specific effect. No other effects were reported for immune-related tissues (NTP, 2018; Klaunig et al., 2015; Chengelis et al., 2009b; Loveless et al., 2009; Kirkpatrick, 2005a).

##### Immune Cell Counts

Five animal studies evaluated hematological indicators of immunotoxicity (NTP, 2018; Klaunig et al., 2015; Chengelis et al., 2009b; Loveless et al., 2009; Kirkpatrick, 2005a). Of these studies, NTP (2018) and Loveless et al. (2009) reported increased neutrophils at doses as low as 20 mg/kg-day and decreased basophils in males receiving ≥250 and 500 mg/kg-day PFHxA or PFHxA sodium salt, respectively. No effects were observed on basophils or neutrophils in the other three rat studies (reproductive, -d90-, and -y2-) at exposures to PFHxA as high as 450 mg/kg-day (Klaunig et al., 2015; Chengelis et al., 2009b; Kirkpatrick, 2005a). Eosinophils were decreased only in males exposed to PFHxA sodium salt for 90 days (Loveless et al., 2009). No other treatment-related effects were reported for specific white blood cell populations or total white blood cell counts following PFHxA or PFHxA sodium salt exposures in rats (NTP, 2018; Klaunig et al., 2015; Chengelis et al., 2009b; Loveless et al., 2009; Kirkpatrick, 2005a). Results are summarized in Figure 3-27.

Figure 3-27 Immune cell counts in rats exposed by gavage to PFHxA or PFHxA sodium salt (HAWC: PFHxA – Animal Toxicity Immune Effects link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-immune-effects/))

Chart displaying immune cell counts in exposed rats.

#### Evidence Integration

The human evidence was limited to one medium confidence study that showed no clear association between PFHxA exposure and immune-related health outcomes, although the authors did observe a nonsignificant trend toward an association with asthma diagnosis in the previous year. Based on these results, there is indeterminate human evidence of immune effects.

Except for changes in thymus weight, the available animal toxicological evidence did not show a clear pattern of effect across studies. Specifically, three studies reported treatment-related changes in thymus and spleen weights in rats, but the direction of effect on spleen weights was not consistent across studies. Extramedullary hematopoiesis was the only histopathological finding of note, but this is interpreted as possibly secondary to the effects on red blood cells rather than an immune-specific effect and is discussed in that context in Section 3.2.4. Increases in neutrophils and decreases in basophils showed a consistent direction of effect across two studies (of the five available). Eosinophils also were decreased, but only in males in a single study. No other treatment-related changes were observed for immune cell counts (i.e., specific cell populations or total white blood cells), and discerning the biological significance of this pattern is difficult in isolation.

The evidence supporting the potential immunotoxicity to humans is limited by several factors, including the lack of consistency across studies for several of the affected outcomes. Furthermore, the evaluated outcomes are limited to changes in the structural components of the immune system, which are less predictive indicators of immunotoxicity (IPCS, 2012). Notably, there is evidence indicating that other PFAS, including PFOS and PFOA, may affect immune system function through suppression of antibody response and induction of hypersensitivity (Dewitt et al., 2019). Additional studies, particularly those that evaluate changes in immune function would be beneficial for understanding the potential for adverse effects of PFHxA exposure on the immune system. Based on these results, there is indeterminate animal evidence of immune effects.

Overall, the currently available evidence is inadequate to determine whether PFHxA exposure might cause immune system effects in humans (see Table 3-35).

Table 3-35 Evidence profile table for immune effects

Evidence stream summary and interpretation | | | | | Evidence integration summary judgment
Evidence from studies of exposed humans | | | | | ⊙⊙⊙; Evidence inadequate; Primary basis:; Evidence is low confidence or limited; Human relevance:; - N/A (indeterminate animal evidence); Cross-stream coherence:; N/A (human evidence indeterminate); Susceptible populations and lifestages:; - No evidence to inform
Studies and confidence | Factors that increase certainty | Factors that decrease certainty | Summary and key findings | Evidence stream judgment
Asthma; 1 medium (https://hawc.epa.gov/summary/visual/assessment/100500070/pfhxa-human-study-evaluation-immune-effects/) confidence study | - No factors noted | - Imprecision; - Lack of coherence – no associations with other measures of pulmonary function | - Nonsignificant association with asthma diagnosis, but other asthma-related outcomes were not affected. | ⊙⊙⊙; Indeterminate
Evidence from animal studies
Studies and confidence | Factors that increase certainty | Factors that decrease certainty | Summary and key findings | Evidence stream judgment
Histopathology; 4 high (https://hawcprd.epa.gov/summary/visual/100500177/) and medium confidence studies in adult rats:; - 28-d; - 90-d; - 2-yr; - Reproductive; 1 low (https://hawcprd.epa.gov/summary/visual/100500177/) confidence study in rats:; - 90-d | - High and medium confidence studies; - Consistency across studies for extramedullary hematopoiesis | - No factors noted | - Increased splenic extramedullary hematopoiesis was observed male and female rats at 500 mg/kg-d; coincident with minimal erythroid hyperplasia of the bone marrow; - Several immune-related histopathology findings reported in male and female rats at 300/450 mg/kg-d, but only in animals with unscheduled deaths | ⊙⊙⊙; Indeterminate; Some evidence of immune system but limited by unexplained inconsistency, lack of coherence, and potential for non-immune related causes [see Section 3.2.4 for additional discussion]. Available evidence was consisted of observational outcomes that are less predictive of immune system toxicity and in one study were only observed in that died or were removed from the study due to overt toxicity.
Immune Cell Counts (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-immune-effects/); 5 high (https://hawcprd.epa.gov/summary/visual/100500177/) and medium confidence studies in rats:; - 28-d; - 90-d (2 studies); - 2-yr; - Reproductive | - High and medium confidence studies; - Consistency–studies for neutrophils and basophils | - Lack of coherence with other immune markers | - Decreased basophil counts and increased neutrophil cell counts at ≥20 mg/kg-d
Organ Weight (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-immune-effects-organ-weigh/); 4 high (https://hawcprd.epa.gov/summary/visual/100500177/) and medium confidence studies in rats:; - 28-d; - 90-d (2 studies); - Reproductive | - High and medium confidence studies | - Unexplained inconsistency across studies for spleen weights | - Thymus weights decreased at 500 mg/kg-d in short-term, subchronic, and reproductive studies; - Changes in spleen weight were inconsistent in the direction of effect across studies
Mechanistic evidence and supplemental information
Biological events of pathways | Biological events of pathways | Biological events of pathways | | Biological events of pathways
- No studies Identified

### 3.2.9 Nervous System Effects

#### Human

No studies were identified that evaluated the effects of PFHxA on the nervous system in humans.

#### Animal

Four short-term (28-day), subchronic, and chronic animal studies evaluated the effects of PFHxA or PFHxA sodium salt in rats. Most outcome-specific study ratings were high or medium confidence. One study was rated low confidence for histopathology due to concerns about observational bias, endpoint sensitivity and specificity, and data presentation (Chengelis et al., 2009b). A summary of the studies and the interpretations of confidence in the results for the different outcomes based on the individual study evaluations is presented in Table 3-36, and details are available by clicking the HAWC link (https://hawcprd.epa.gov/summary/visual/100500177/).

Table 3-36 Nervous system endpoints for PFHxA and associated confidence scores from repeated-dose animal toxicity studies

Author (year) | Species, strain (sex) | Exposure design | Exposure route and dose range | Brain weight | Histopathology | Behavior
NTP (2018) | Rat, Harlan Sprague-Dawley (male and female) | Short term (28 d) | Gavage^a^; Male and female: 0, 62.5, 125, 250, 500, 1,000 mg/kg-d | ++ | ++ | NM
Chengelis et al. (2009b) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | Subchronic (90 d) | Gavage^a^; Male and female: 0, 10, 50, 200 mg/kg-d | ++ | − | +
Loveless et al. (2009) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | Subchronic (90 d) | Gavage^b^; Male and female: 0, 20, 100, 500 mg/kg-d | ++ | ++ | ++
Klaunig et al. (2015) | Rat, Crl:CD(SD) Sprague-Dawley (male and female) | 2-yr cancer bioassay | Gavage^a^; Male: 0, 2.5, 15, 100 mg/kg-d; Female: 0, 5, 30, 200 mg/kg-d | NM | ++ | ++

++ Outcome rating of high confidence; + outcome rating of medium confidence; − outcome rating of low confidence; NM, outcome not measured.

a,b Study evaluation for animal toxicological nervous system endpoints reported from studies with male and female rats receiving PFHxA^a^ or PFHxA sodium salt^b^ by gavage. Study evaluation details for all outcomes are available by clicking the HAWC link (https://hawcprd.epa.gov/summary/visual/100500177/).

##### Brain Weight

Three studies evaluated effects of PFHxA or PFHxA sodium salt on the nervous system in animals (NTP, 2018; Chengelis et al., 2009b; Loveless et al., 2009). Two studies reported increases in relative but not absolute brain weights after exposure to PFHxA or PFHxA sodium salt for 28 or 90 days, respectively (Chengelis et al., 2009b; Loveless et al., 2009). These effects were observed at the highest dose tested (200 or 500 mg/kg-day) and affected only males in one study (Loveless et al., 2009) and only females in the other (Chengelis et al., 2009b). Notably, relative weights are not considered appropriate for brain weight measurements because this measure is not typically affected by fluctuations in body weight (U.S. EPA, 1998); therefore, absolute brain weights are preferred.

##### Other Nervous System Effects

No treatment-related effects were observed on other nervous system outcomes, including behavior (i.e., open field locomotor activity, functional observational battery) and histopathology (NTP, 2018; Klaunig et al., 2015; Chengelis et al., 2009b; Loveless et al., 2009).

#### Mechanistic Evidence and Supplemental Information

Two studies evaluated effects of PFHxA exposure on neurodevelopment in zebrafish using wildtype (Guo et al., 2021; Gaballah et al., 2020) and transgenic [Tg (HuC-GFP)] (Guo et al., 2021) strains exposed during embryonic and early larval development. Both reported effects on larval swimming behavior, with larvae showing an increase in swimming activity at low to moderate doses but no effect at the higher doses. Guo et al. (2021) evaluated several other nervous system related outcomes in wildtype larvae, including acetylcholinesterase activity, and neurotransmitter levels. Acetylcholinesterase activity was statistically significantly reduced at all dose levels. Treatment-related effects on neurotransmitter levels was largely limited to the high exposure group (12 mg/L), with dopamine, DOPAC, and GABA levels showing 92% to 174% increases relative to controls. Acetylcholine was slightly reduced in the 2.4 mg/L exposure group and there was no effect on serotonin. A transgenic strain, Tg (HuC-GFP), that expresses GFP in neuronal cells was used to evaluate effects on neurodevelopment and proliferation in the central nervous system in vivo. Larvae in the high exposure group showed a 48% decreased in GFP expression, but there were no effects in the lower exposure groups.

Two studies evaluated effects on expression of genes and proteins related to neurodevelopment in primary avian neuronal cells (Vongphachan et al., 2011) and larval zebrafish (Guo et al., 2021). Only one gene was evaluated in both studies. mbp, which is essential for myelination of nerves, showed increased expression in both models, although this was only observed at the lowest tested concentration in the zebrafish study. Guo et al. (2021) examined 17 additional genes that are involved in various aspects of nervous system function and development in zebrafish larvae exposed up to 120 hours post fertilization. The results are summarized in in Table 3-37. Statistically significant changes in gene expression were reported for every gene. Although some genes showed increased expression (mbp, dat, bdnf, nr4a2b), most were decreased. Protein expression data from the same study provide some support for these results. ɑ1-tubulin, elavl3, and gap43 protein levels were reduced in animals exposed to med or high concentrations showing a similar pattern and direction of effect as the gene expression results. Vongphachan et al. (2011) also measured effects on rc3, which is important for Ca2+ signal transduction and may play a role in long term potentiation but found no treatment-related effects.

Table 3-37 Changes in expression of genes related to neurodevelopment in early life stage zebrafish

Gene | Function/Role | 0.48 mg/L PFHxA | 2.4 mg/L PFHxA | 12 mg/L PFHxA
chrna7 | Acetylcholine receptor | – | – | ↓
ache | Acetylcholinesterase | – | ↓ | ↓
mbp | Myelination | ↑ | – | –
α1-tubulin | Axon/dendrite growth | – | – | ↓
shha | Axon growth | – | ↓ | ↓
elavl3 | Differentiation of ganglion, amacrine cells | – | – | ↓
gap43 | Synaptogenesis; axon development/regeneration | – | ↓ | ↓
syn2a | Synaptogenesis | ↑ | ↑ | ↓
gfap | Astroglia development | – | – | ↓
th2 | Serotoninergic neuron marker | ↓ | ↓ | –
htr1ab | Serotonin receptor | ↓ | ↓ | ↓
htr1b | Serotonin receptor | ↓ | ↓ | ↓
htr2a | Serotonin receptor | ↓ | ↓ | ↓
htr1aa | Serotonin receptor | ↓ | ↓ | ↓
htr5a | Serotonin receptor | – | – | ↓
dat | Dopamine reuptake | – | – | ↑
bdnf | Neuronal differentiation | ↑ | ↑ | –
nr4a2b | Development of dopaminergic neurons | ↑ | ↑ | ↑

–, no statistically significant change relative to control; ↓, statistically significant decrease relative to control; ↑, statistically significant increase relative to control.

#### Evidence Integration

No human studies were identified to inform the potential nervous system effects of PFHxA or PFHxA salts; therefore, there is indeterminate human evidence of nervous system effects.

In animals, the only available evidence to support an effect of PFHxA or PFHxA salts the nervous system stems from increase in relative brain weights, which is not considered a reliable measure of neurotoxicity (U.S. EPA, 1998). No treatment-related effects were reported for other nervous system outcomes.

Although the available animal toxicity data are largely null and derived from low risk of bias studies, some uncertainties and data gaps remain. The results are limited to a small number of studies in adult animals, and the evidence base is lacking studies that could inform potential for nervous system effects when exposure occurs during development. This lifestage is a known critical window of sensitivity for nervous system effects (U.S. EPA, 1998) and has been identified as a research area of potential concern for other PFAS known to affect thyroid function. Two studies provide limited mechanistic evidence and supporting information suggesting the potential for neurodevelopmental effects of PFHxA. Based on these results, there is indeterminate animal evidence of nervous system effects and additional studies would be necessary to draw a more definitive judgment.

Overall, the currently available evidence is inadequate to assess whether PFHxA might cause nervous system effects in humans (see Table 3-38).

Table 3-38 Evidence profile table for nervous system effects

Evidence stream summary and interpretation | | | | | Evidence integration summary judgment
Evidence from studies of exposed humans | | | | | ⊙⊙⊙; Evidence inadequate; Primary Basis:; No evidence in humans and animal evidence is largely null or lacking biological relevance.; Human relevance:; N/A (indeterminate animal evidence); - Cross stream coherence:; N/A (human evidence indeterminate).; Susceptible populations and lifestages:; No evidence to inform.; Other inferences:; Some mechanistic data and supplemental information were identified that provide limited support for potential PFHxA mediated nervous system effects. These were limited to neurodevelopmental models for which there are no available animal data and there are insufficient to inform a potential MOA.
Studies and confidence | Factors that increase certainty | Factors that decrease certainty | Summary and key findings | Strength of evidence
- No studies identified | | | | ⊙⊙⊙; Indeterminate
Evidence from animal studies
Studies and confidence | Factors that increase certainty | Factors that decrease certainty | Summary and key findings | Strength of evidence summary
Brain Weight; 3 high (https://hawcprd.epa.gov/summary/visual/100500177/) confidence studies in adult rats:; - 28-d; - 90-d (2 studies) | - High confidence studies | - No factors noted | - Increased relative brain weights (preferred metric) in animals at ≥200 mg/kg-d; absolute brain weight unaffected | ⊙⊙⊙; Indeterminate; Evidence is largely null. The only evidence of nervous system effects was relative brain weight increases, which is not considered to be appropriate for evaluating nervous system toxicity.
Histopathology; 3 high (https://hawcprd.epa.gov/summary/visual/100500177/) confidence studies in adult rats:; - 28-d; - 90-d; - 2-yr; 1 low confidence study in adult rats:; - 90-d | - High confidence studies | - No factors noted | - No treatment-related effects reported
Behavior; 2 high (https://hawcprd.epa.gov/summary/visual/100500177/) confidence studies in adult rats:; - 90-d; - 2-yr; 1 medium (https://hawcprd.epa.gov/summary/visual/100500177/) confidence study in adult rats:; - 90-d | - High and medium confidence studies | - No factors noted | - No treatment-related effects reported
Mechanistic evidence and supplemental information
Biological events or pathways | Key findings, interpretation, and limitations | | | Evidence stream summary
Behavior | Key findings and interpretation:; - Alterations in larval swimming activity observed following early life exposure in zebrafish; - Increased swimming activity at low to moderate exposure levels in two studies; - Statistically significant effects seen mostly at lowest exposure level; Limitations:; - Small evidence base with effects not showing a clear dose response | | | Some support for potential effects of PFHxA on neurodevelopment, but these are largely limited to a single study in early life stage zebrafish.
Neurodevelopment | Key findings and interpretation:; - Neuron-specific GPF expression statistically significantly reduced in vivo in larval zebrafish, suggesting treatment-related effects on neuro proliferation; - Effects only observed in high exposure group; Limitations:; - Small evidence base | | | Some support for potential effects of PFHxA on neurodevelopment, but these are largely limited to a single study in early life stage zebrafish.
Acetylcholinesterase Activity | Key findings and interpretation:; - Decreased acetylcholinesterase activity observed in larval zebrafish at in all dose groups; Limitations:; - Small evidence base | | | Some support for potential effects of PFHxA on neurodevelopment, but these are largely limited to a single study in early life stage zebrafish.
Neurotransmitter Levels | Key findings and interpretation:; - Altered neurotransmitter levels in whole body zebrafish larvae observed at all dose levels; Limitations:; - Small evidence base | | | Some support for potential effects of PFHxA on neurodevelopment, but these are largely limited to a single study in early life stage zebrafish.
Gene and Protein Expression | Key findings and interpretation:; - Changes observed in 18 genes and 3 proteins related to nervous system function and development in larval zebrafish; - Decreases in both gene and protein expression for ɑ1-tubulin, elavl3, and gap43 in zebrafish; - Two studies in zebrafish and avian neuronal cells found decreases in gene expression of mbp, but no clear dose response in zebrafish (low exposure group only); Limitations:; - Small evidence base | | | Some support for potential effects of PFHxA on neurodevelopment, but these are largely limited to a single study in early life stage zebrafish.

## 3.3 CARCINOGENICITY

### 3.3.1 Cancer

#### Human Studies

One low confidence case-control study of breast cancer and PFHxA exposure is available in humans (Velarde et al., 2022). This study reported a positive association in the fourth quartile (OR = 2.66, 95% CI: 0.95-7.66 vs. Q1), but the association was non-monotonic across quartiles (inverse associations were reported in the second and third quartiles) and there were serious concerns for potential selection bias and exposure misclassification (due to lack of temporality in exposure measurement), so there is considerable uncertainty in this finding.

#### Animal Studies

A high confidence cancer bioassay conducted in rats evaluated neoplastic and non-neoplastic lesions in the lungs, kidney, stomach, and liver of male rats dosed with 0, 2.5, 15, or 100 mg/kg-day and in female rats dosed with 0, 5, 30, or 200 mg/kg-day (Klaunig et al., 2015). Findings for nonneoplastic and neoplastic lesions were reported as null and are summarized in HAWC (https://hawcprd.epa.gov/ani/animal-group/100500464/) and in PFHxA Tableau (https://public.tableau.com/profile/literature.inventory#!/vizhome/PerfluorohexanoicAcidPFHxAEvidenceMapVisualization/AnimalStudies).

#### Genotoxicity

Genotoxic, mutagenic, and clastogenic effects of PFHxA have been tested in several mammalian and prokaryotic cell systems in vitro (see Table 3-39) (Eriksen et al., 2010; Nobels et al., 2010; Loveless et al., 2009). Sodium perfluorohexanoate (NaPFHx) was negative for mutagenicity in Escherichia coli strain WP2uvrA and Salmonella typhimurium strains TA98, TA100, TA1535, and TA1537 in both the presence and absence of exogenous S9 metabolic activation (Loveless et al., 2009). Nobels et al. (2010) examined the ability of PFHxA to induce the expression of 14 prokaryotic stress response genes after exposure of the E. coli K-12 derivative SF_1_ to 0.0156–1 mM PFHxA. The results of this study demonstrated that PFHxA did not significantly induce the expression of regulatory elements critical for the prokaryotic gene expression response to oxidative stress (katG, zwf, soi28, and nfo), membrane damage (micF and osmY), general cell lesions (uspA and clpB), heavy metal stress (merR), and DNA damage (nfo, recA, umuDC, ada, sfiA, and dinD). In mammalian cells in vitro, PFHxA did not generate reactive oxygen species (ROS) or oxidative deoxyribonucleic acid damage in the human hepatoma cell line, HepG2 (Eriksen et al., 2010). Lastly, NaPFHx failed to induce chromosomal aberrations in human peripheral blood lymphocytes in the presence and absence of exogenous metabolic activation, suggesting a lack of clastogenic activity (Loveless et al., 2009).

#### Evidence Integration

A single low confidence human study reported a positive association between PFHxA exposure measures and breast cancer; however, this association was limited to the fourth quartile with inverse associations reported for the second and third quartiles (Velarde et al., 2022). In animals, one study (Klaunig et al., 2015) evaluated the potential carcinogenicity of oral PFHxA exposure via histological evaluation of the lung, kidney, stomach, and liver of male rats, and did not observe significant treatment-related effects, and the few studies examining markers of potential genotoxicity were largely null. No studies of potential carcinogenicity in via other exposure routes were identified. Given the sparse and notably uncertain evidence base, and in accordance with the Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005) EPA concluded there is inadequate information to assess carcinogenic potential for PFHxA for any route of exposure.

Table 3-39 Summary of PFHxA genotoxicity studies

PFHxA genotoxicity
Endpoint | Test system | Doses/concentrations tested | Results^a^ | | Comments | References
Endpoint | Test system | Doses/concentrations tested | Without exogenous activation | With exogenous activation | Comments | References
ROS production | HepG2 (human hepatoma cell line) | 0.4, 4, 40, 200, 400, 1,000, 2,000 µM | – | NA | Intracellular reactive oxygen species (ROS) production was measured using 2’,7’-dichlorofluorescein diacetate. ROS production was measured every 15 min for 3 hr. No clear concentration-response relationship was observed for PFHxA, whereas exposure to H_2_O_2_ (positive control) generated ROS in a concentration dependent manner. | Eriksen et al. (2010)
DNA damage | HepG2 (human hepatoma cell line) | 100, 400 µM | – | NA | Comet assay to detect the formation of DNA strand breaks (including alkali-labile sites) and formamidopyrimidine-DNA-glycosylase sensitive sites after 24-hr exposure. Cytotoxicity was monitored by measuring lactate dehydrogenase (LDH) activity to ensure observed DNA damage was not secondary to cytotoxicity. | Eriksen et al. (2010)
Cell stress-dependent gene expression | Escherichia coli; K-12 derivative SF_1_ | 0.0156, 0.03125, 0.0625, 0.125, 0.25, 0.5, 1 mM | – | NA | Promoters of 14 prokaryotic DNA-damage responsive genes were fused to lacZ cassettes and expressed in E. coli. Activation of gene expression was measured after 90 min of exposure by β-galactosidase reduction capacity and spectrophotometrically at 420 nm. Genes involved in prokaryotic DNA damage and repair (umuDC and ada) were upregulated at approximately ≥1.4-fold but did not reach statistical significance at any dose. Study authors did not provide complete data for analysis. | Nobels et al. (2010)
Mutation (Ames assay) | Salmonella typhimurium strains TA98, TA100, TA1535, and TA1537 | 333, 667, 1,000, 3,333, 5,000 µg/plate sodium perfluorohexanoate (NaPFHx) | – | – | Assay performed according to OECD Guideline 471. No positive mutagenic responses were observed at any dose level or with any tester strain in the presence or absence of S9 metabolic activation. | Loveless et al. (2009)
Mutation | E. coli; WP2uvrA | 333, 667, 1,000, 3,333, 5,000 µg/plate sodium perfluorohexanoate (NaPFHx) | – | – | Assay performed according to OECD Guideline 471. No positive mutagenic responses were observed at any dose level or with any tester strain in the presence or absence of S9 metabolic activation. | Loveless et al. (2009)
Chromosomal aberration | Human peripheral blood lymphocytes | 4h (nonactivated): 2,000, 3,000, 3,860 µg/mL sodium perfluorohexanoate (NaPFHx); 4 hr (activated) and 22 hr (nonactivated): 250, 500, 1,000 µg/mL sodium perfluorohexanoate (NaPFHx) | – | – | Assay performed according to OECD Guideline 473. Percentage of cells with structural or numerical aberrations was not significantly increased above that of the vehicle control at any concentration. Aroclor-induced rat liver S9 was used for exogenous metabolic activation. Mitomycin C and cyclophosphamide were used as positive controls. Substantial toxicity (defined as a reduction in the mitotic index of >50% in the NaPFHx treated cell culture as compared to vehicle control) was observed in all test conditions. | Loveless et al. (2009)
Cell Proliferation and neoplastic transformation | Human breast epithelial cells (MCF-10A) | 500 pM, 1 nM, 10 nM, 100 nM, 500 nM, 1 μM, 10 μM, 100 μM, 500 μM | – | – | Cell proliferation was inferred from cell viability (measured by the MTT assay) and cell counting after 72 hrs PFAS treatment. No alterations were identified for PFHxA at any of the concentrations tested.; Neoplastic transformation was measured by transwell migration and invasion assays. No positives were identified for PFHxA compared to controls at any of the concentrations tested. | (Pierozan et al., 2022)
DNA damage in sperm | Human sperm cells obtained from nonsmoker healthy men (n = 3, 27–34 yr old) | 100 μM, 300 μM, 1000 μM | – | – | DNA damage was analyzed using the alkaline comet assay. No significant DNA damage was identified in human sperm cells treated with PFHxA. | (Emerce and Çetin, 2018)

a − = negative; NA = not applicable.

5 The “sufficient exposure conditions” are more fully evaluated and defined for the identified health effects through dose-response analysis in Section 5.

6 The “sufficient exposure conditions” are more fully evaluated and defined for the identified health effects through dose-response analysis in Section 5.

7 The “sufficient exposure conditions” are more fully evaluated and defined for the identified health effects through dose-response analysis in Section 5.

8 The “sufficient exposure conditions” are more fully evaluated and defined for the identified health effects through dose-response analysis in Section 5.