# 2 SUMMARY OF LITERATURE IDENTIFICATION AND STUDY EVALUATION RESULTS

## 2.1 LITERATURE SEARCH AND SCREENING RESULTS

The evidence base searches yielded 975 unique records identified from core database searches (WOS, Toxline, PubMed, Toxnet) and other sources (see Figure 2-1). Of the 975 studies identified, 74 were excluded at the title and abstract level on the basis that they did not meet the PECO and did not contain potentially relevant supplemental information. At the full-text level, 57 studies met PECO criteria including 24 human health effect studies, 23 in vivo animal studies, 7 genotoxicity study, and 5 PBPK/PK studies (see Table 1-3). An interactive summary of the literature screening results is available as a literature tag-tree accessible via the link: PFHxA Literature Tagtree (https://hawc.epa.gov/lit/assessment/100500070/references/visualization/). Additional information, including high-throughput screening data on PFHxA, are available from EPA’s CompTox Chemicals Dashboard (https://comptox.epa.gov/dashboard) (U.S. EPA, 2018a).

Figure 2-1 Literature search and screening flow diagram for PFHxA and related salts, PFHxA-NH_4_ and PFHxA-Na

Literature HAWC tree are available in HAWC (https://hawc.epa.gov/lit/assessment/100500070/references/visualization/) and all studies are available in PFHxA HERO (https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/2628).

PFHxA-NH_4_ = ammonium perfluorohexanoate; PFHxA-Na = sodium perfluorohexanoate.

Literature search and screening flow diagram.

## 2.2 STUDY EVALUATION RESULTS

Human and animal studies evaluated potential hepatic, developmental, hematopoietic, endocrine, cardiometabolic, renal, reproductive, immune, and nervous system effects following exposure to PFHxA. The evidence informing these potential health effects is presented and assessed in Sections 3.2.1−3.2.9. Seventeen epidemiological studies were identified that report on the potential association between PFHxA and human health effects. Of these, five were considered uninformative due to critical deficiencies in one or more domains, including participant selection, exposure measurement, confounding, or analysis (Zhang et al., 2019; Seo et al., 2018; Kim et al., 2016a; Jiang et al., 2014). The remaining 12 studies were rated medium (Liu et al., 2022; Nian et al., 2019; Bao et al., 2017; Zeng et al., 2015; Dong et al., 2013) or low confidence (Velarde et al., 2022; Tian et al., 2019; Wang et al., 2019; Song et al., 2018; Li et al., 2017; Zhou et al., 2016; Fu et al., 2014).

Seven unique reports of animal studies met PECO criteria. The available evidence base of animal toxicity studies on PFHxA and the related ammonium and sodium salts primarily consists of five reports in rats and mice including short-term (NTP, 2018), subchronic (Chengelis et al., 2009b; Loveless et al., 2009), chronic (Klaunig et al., 2015), and reproductive/developmental (Iwai and Hoberman, 2014; Loveless et al., 2009) experiments. These studies were generally well conducted and judged high or medium confidence. In cases where a study was rated low confidence for one or more of the evaluated outcomes, the specific limitations identified during evaluation are discussed in the applicable synthesis section(s). An acute (<24 hours) oral toxicity study was also available (Riker Labs, 1979) but not considered informative as other longer duration (>30 day) studies were available. A reproductive study by Kirkpatrick (2005a) was initially considered uninformative due to reporting deficiencies (i.e., all summary and individual animal data [pages 110−1,334] were missing). During public comment, the study sponsor submitted the missing data tables (Kirkpatrick, 2005a, b, c, d, e, f, g). Consistent with the protocol and the study was reconsidered for incorporation in the assessment based on the potential impact on assessment conclusions. The study was considered medium confidence for most outcomes. Immune findings from this study were incorporated into the evidence synthesis on the basis that, although they do not change the assessment conclusions, they may help to address critical data gaps for this potential health effect. For all other health effects it was determined that the data would not impact assessment conclusions based on the following rationales: for reproductive, developmental and renal effects, the findings were weak or null and did not address key data gaps; for hepatic and hematopoietic effects, the results were similar to effects observed in other studies and supported hematopoietic and hepatic conclusions (i.e., decreased hemoglobin, MCH, MCHC, total protein, globulin; increased relative liver weight, incidence of hepatocellular hypertrophy), but largely limited to the high dose that was associated with overt toxicity, including high mortality (approx. 33%) which may impact the reliability of the results. Thus, these findings were not incorporated into the evidence synthesis and integration sections for hepatic, hematopoietic, developmental, renal, and reproductive health effects.

Detailed rationales for each domain and overall confidence rating are available in HAWC (https://hawcprd.epa.gov/assessment/100500070/). Results shown below in Figure 2-2 for human studies are (interactive version available: link (https://hawcprd.epa.gov/summary/visual/100500176/)) and Figure 2-3 for animal studies (interactive version available: link (https://hawcprd.epa.gov/summary/visual/100500177/)). Graphical representations of the outcome-specific ratings are also presented in the organ/system-specific integration sections (in Section 3.2). All outcomes rated low confidence or higher were used for evidence synthesis and integration.

Figure 2-2 Study evaluation results for human epidemiology studies

Grid diagram of epidemiology study results.

Figure 2-3 Study evaluation results for animal toxicology studies

Grid diagram of study evaluation results.