# 1 OVERVIEW OF BACKGROUND INFORMATION AND ASSESSMENT METHODS

A series of five PFAS assessments (perfluorobutanoic acid [PFBA], perfluorohexanoic acid [PFHxA], perfluorohexane sulfonate [PFHxS], perfluorononanoic acid [PFNA], perfluorodecanoic acid [PFDA], and their associated salts) are being developed by the Integrated Risk Information System (IRIS) Program at the request of the U.S. Environmental Protection Agency (EPA) National Programs and Regions. Appendix A is the systematic review protocol for these five PFAS assessments. The protocol outlines the scoping and problem formulation efforts relating to these assessments, including a summary of other federal and state reference values for PFHxA. The protocol also lays out the systematic review and dose-response methods used to conduct this review (see also Section 1.2). This systematic review protocol was released for public comment in November 2019 and was subsequently updated based on those public comments. Appendix A includes the updated version of the protocol, including a summary of the updates in the protocol history section (see Appendix A, Section 12).

## 1.1 BACKGROUND INFORMATION ON PFHxA AND RELATED AMMONIUM AND SODIUM SALTS

This section provides a brief overview of aspects of the physiochemical properties, human exposure, and environmental fate characteristics of perfluorohexanoic acid (PFHxA, CASRN 307-24-4), ammonium perfluorohexanoate (PFHxA-NH_4_, CASRN 21615-47-4), and sodium perfluorohexanoate (PFHxA-Na, CASRN 2923-26-4). This overview is not intended to provide a comprehensive description of the available information on these topics and is not recommended for use in decision making. The reader is encouraged to refer to source materials cited below, more recent publications on these topics, and the assessment systematic review protocol (see Appendix A).

### 1.1.1 Physical and Chemical Properties

PFHxA and related sodium and ammonium PFHxA salts covered in this assessment are members of the group of per- and polyfluoroalkyl substances (PFAS). Concerns about PFHxA and other PFAS stem from the resistance of these compounds to hydrolysis, photolysis, and biodegradation, which leads to their persistence in the environment (NLM, 2017, 2016, 2013). PFHxA and related salts are classified as a perfluorinated carboxylic acids (PFCAs) (OECD, 2015). PFHxA and its associated salts are considered short-chain PFAS (ATSDR, 2021). The linear chemical structures^2^ of these chemicals are presented in Figure 1-1, and select physiochemical properties are provided in Table 1-1. When available, experimental values are provided in the table but predicted values that may be less reliable are included in the absence of experimental data.

Figure 1-1 Linear chemical structures of (from left to right) PFHxA, PFHxA NH_4_, and PFHxA-Na

PFHxA = perfluorohexanoic acid; PFHxA NH_4_ = ammonium perfluorohexanoate; PFHxA-Na = sodium perfluorohexanoate.

Chemical structure diagrams.

Source: EPA CompTox Chemicals Dashboard (https://comptox.epa.gov/dashboard).

Table 1-1 Physicochemical properties of PFHxA

Property (unit) | PFHxA value | PFHxA-NH_4_ value | PFHxA-Na value
Formula | C_6_HF_11_O_2_C_6_HF_11_O_2_ | C_6_H_4_F_11_NO_2_ | C_6_F_11_NaO_2_
Molecular weight (g/mol) | 314 | 331 | 336
Melting point (°C) | 12.2^a^ | 39.2^b^ | 70.2^b^
Boiling point (°C) | 157^a^ | 156^b^ | 216^b^
Density (g/cm^3^) | 1.69^b^ | 1.72^b^ | 1.69^b^
Vapor pressure (mm Hg) | 0.908^a^ | 2.00^b^ | 1.63^b^
Henry’s law constant (atm-m^3^/mole) | 2.35 × 10^−10(b)^ | 2.35 × 10^−10(b)^ | 2.35 × 10^−10(b)^
Water solubility (mol/L) | 9.34 × 10^−5(a)^ | 1.10^b^ | 8.78 × 10^−5(a)^
PKa | −0.16^c^ | – | –
LogP_Octanol-Water_^d^ | 2.85^a^ | 3.97^b^ | 0.70^a^
Soil adsorption coefficient (L/kg) | 1,070^b^ | 1,070^b^ | 1,070^b^
Bioconcentration factor | 49.3^b^ | 5.47^b^ | 49.3^b^

“–” = data not available.

a (U.S. EPA, 2018a). CompTox Chemicals Dashboard (https://comptox.epa.gov/dashboard); access date 2/18/2021. Median or average experimental values.

b Average or median predicted values are, in general, less reliable than experimental values.

c Predicted value reported by Steinle-Darling and Reinhard (2008).

d Experimental measure of PFAS octanol/water partition coefficient are difficult due to the tendency for alkyl acids to aggregate at the interface between octanol and water (Kim et al., 2015).

### 1.1.2 Sources, Production, and Use

PFAS have been used widely over the past several decades in consumer products and industrial applications because of their resistance to heat, oil, stains, grease, and water. (ATSDR, 2021; U.S. EPA, 2020, 2019c, 2013, 2007, 2002b). Fluorinated compounds have also been used in consumer products including stain-resistant fabrics for clothing, carpets, and furniture; nonstick cookware; ski wax; certain leather products; and personal care products (e.g., dental floss, cosmetics, and sunscreen) (ATSDR, 2021; U.S. EPA, 2020, 2019c, 2013, 2007, 2002b). PFAS also have been detected from foam used in firefighting and in industrial surfactants, emulsifiers, wetting agents, additives, and coatings; they are also used in aerospace, automotive, building, and construction industries to reduce friction (U.S. EPA, 2020, 2019c; ATSDR, 2018; U.S. EPA, 2013, 2007, 2002b). PFHxA has been detected as a breakdown product of PFAS used in water- and stain-protective coatings for carpets, paper, and textiles including textiles used in some protective clothing (Klaunig et al., 2015). PFAS have been found at private and federal facilities associated with various material or processes involving aqueous film-forming foam (AFFF), chrome plating, and are associated with other industries using PFAS (e.g., textiles, carpets) (ATSDR, 2021; U.S. EPA, 2020, 2019c, 2013, 2007, 2002b). In AFFF, PFHxA has been detected at concentrations ranging from 0.1 to 0.3 g/L (Baduel et al., 2015; Houtz et al., 2013). In the occupational sectors and/or products PFAS occurances have been found in wood particle board, rubber insulation, electroplating, metal treatments, paints, varnishes, and flame retardants (OECD, 2022; Glüge et al., 2020).

No quantitative PFHxA information on production volume is available (U.S. EPA, 2019a), and EPA’s Toxics Release Inventory (TRI) contains no information on releases to the environment from facilities manufacturing, processing, or otherwise using PFHxA (ATSDR, 2021; U.S. EPA, 2018d).

Wang et al. (2014) estimates global emissions of 39 to 1,691 tons of PFHxA from direct and indirect (i.e., degradation of precursors) sources between 1951 and 2030. The lower estimate assumes manufacturers cease production and use of long-chain PFCAs and that their precursors stay consistent with global transition trends. The higher estimate assumes the 2015 emission scenario remains constant until 2030.

### 1.1.3 Environmental Fate and Transport

PFAS are highly stable and persistent worldwide, and many are found in environmental media (e.g., soils, water, the atmosphere, foods, wildlife, and humans) (U.S. EPA, 2019c) (Appendix A).

Uptake of soil PFAS to plants can occur (ATSDR, 2021), and estimates are available of PFAS accumulation in vegetation when plants are grown in PFAS-contaminated soil. Yoo et al. (2011) estimated grass-soil accumulation factors of 3.4 (grass concentration divided by soil concentration) for PFHxA using samples collected from a site with biosolids-amended soil. Venkatesan and Halden (2014) analyzed archived samples from outdoor mesocosms to investigate the fate over 3 years of PFAS in agricultural soils amended with biosolids. The mean half-life for PFHxA was estimated to be 417 days. Volatilization of PFHxA from moist soil is not expected to be an important fate process (NLM, 2016). PFHxA bioaccumulates in foods grown on PFAS-containing soils. Blaine et al. (2013) conducted a series of greenhouse and field experiments to investigate the potential for PFAS uptake by lettuce, tomatoes, and corn when grown in industrially impacted and biosolids-amended soils. Blaine et al. (2013) calculated PFHxA bioaccumulation factors of 9.9–11.7 for lettuce and 2.9–6.8 for tomatoes (no bioaccumulation factor was reported for corn).

### 1.1.4 Potential for Human Exposure and Populations with Potentially Greater Exposure

The general population can be exposed to PFAS via inhalation of air or dust, ingestion of drinking water and food, and dermal contact with PFAS-containing products and during susceptible lifestages (see Appendix A). The oral route of exposure is considered the dominant exposure pathway for the general population (Sunderland et al., 2019), for which contaminated drinking water is likely a significant source of exposure to PFAS, including PFHxA. Due to the high water solubility and mobility of PFAS in groundwater (and potential lack of remediation at some water treatment facilities), populations consuming drinking water from any contaminated watershed could be exposed to PFAS (Shao et al., 2016).

Infants potentially have higher exposure due to greater ingestion of food per body weight. PFHxA has been detected in human breast milk from many nations, including U.S. (Zheng et al., 2021), French, Korean, and Spanish populations (summarized in Table 5 of Anderson et al. (2019)). Exposure can also occur through hand-to-mouth transfer of materials containing these compounds (ATSDR, 2021) or in infants through ingestion of formula reconstituted with contaminated drinking water.

#### Air and Dust

PFHxA has not been evaluated under the National Air Toxics Assessment program (https://www.epa.gov/national-air-toxics-assessment) and no additional information on atmospheric concentration was identified. PFAS, including PFHxA, have been measured in indoor air and dust and might be associated with the indoor use of consumer products such as PFAS-treated carpets or other textiles (ATSDR, 2021). For example, Kato et al. (2009) detected PFHxA in 46.2% of the dust samples collected from 39 homes in the United States, United Kingdom, Germany, and Australia. Karásková et al. (2016) detected PFHxA in all 56 dust samples collected from 41 homes in the Czech Republic, Canada, and the United States at mean concentrations of 12.8, 14.5, and 20.9 ng/g, respectively. Strynar and Lindstrom (2008) analyzed dust samples from 110 homes and 10 daycare centers in North Carolina and Ohio and detected PFHxA in 92.9% of the samples. Knobeloch et al. (2012) detected PFHxA in 20% of samples of vacuum cleaner dust collected from 39 homes in Wisconsin. PFHxA concentrations ranged from below the reporting limit (1 ng/g) to 180 ng/g. Fraser et al. (2013) analyzed dust samples collected from offices (n = 31), homes (n = 30), and vehicles (n = 13) in Boston, Massachusetts. PFHxA was detected in 68% of the office samples at concentrations ranging from 5.1 to 102 ng/g, 57% of the home samples at concentrations ranging from 4.9 to 1,380 ng/g, and 54% of the vehicle samples at concentrations ranging from 5.0 to 18.2 ng/g.

#### Water

EPA conducted monitoring for several PFAS in drinking water as part of the third and fifth Unregulated Contaminant Monitoring Rules (UCMR3 and UCMR5) (U.S. EPA, 2019b, 2016d). PFHxA was added to UCMR5 for public water system monitoring, which applies to 2022–2026 with sample collection occurring between 2023 and 2025. Some drinking water PFHxA data are available from other publications. For example, samples from seven municipal wells in Oakdale, Minnesota were analyzed for PFHxA where the concentrations ranged from <0.025 to 0.235 µg/L (U.S. EPA, 2016d). PFHxA was also detected in 23% of raw water samples collected from public water systems in New Jersey at concentrations ranging from nondetectable to 0.017 µg/L (Post et al., 2012). In a more recent study of surface waters sampled from 11 waterways in New Jersey, PFHxA was detected in 10 samples, ranging from 0.0015 to 0.026 µg/L (Goodrow et al., 2020).

#### AFFF Training Sites

PFHxA was detected at an Australian training ground where AFFFs had been used. Baduel et al. (2015) and Bräunig et al. (2017) observed mean concentrations of PFHxA of 0.6 µg/L in water, 8.4 µg/kg dry weight in soil, and 3.0 µg/kg wet weight in grass at an Australian town where the groundwater had been impacted by PFAS from a nearby firefighting training facility. Houtz et al. (2013) analyzed samples of groundwater, soil, and aquifer solids collected at an Air Force firefighting training facility in South Dakota where AFFF had been used. PFAS concentrations in groundwater decreased with increased distance from the burn pit, and PFHxA was detected at a median concentration of 36 µg/L. PFHxA was detected in surficial soil at a median concentration of 11 µg/kg and in aquifer solids at a median concentration of 45 µg/kg.

#### Military and National Priorities List (NPL) Sites

PFHxA levels in environmental samples collected in 2014 have been measured at military and National Priorities List (NPL) sites in the United States. Table 1-2 provides the concentrations at these sites (ATSDR, 2021; Anderson et al., 2016).

Table 1-2 PFHxA levels at 10 military installations and National Priority List sites

Media | PFHxA value | Site | Source
Surface soil | | Military^a^ | Anderson et al. (2016)
Frequency of detection (%) | 70.33 | Military^a^ | Anderson et al. (2016)
Median (ppb) | 1.75 | Military^a^ | Anderson et al. (2016)
Maximum (ppb) | 51.0 | Military^a^ | Anderson et al. (2016)
Subsurface soil | | Military^a^ | Anderson et al. (2016)
Frequency of detection (%) | 65.38 | Military^a^ | Anderson et al. (2016)
Median (ppb) | 1.04 | Military^a^ | Anderson et al. (2016)
Maximum (ppb) | 140 | Military^a^ | Anderson et al. (2016)
Sediment | | Military^a^ | Anderson et al. (2016)
Frequency of detection (%) | 63.64 | Military^a^ | Anderson et al. (2016)
Median (ppb) | 1.70 | Military^a^ | Anderson et al. (2016)
Maximum (ppb) | 710 | Military^a^ | Anderson et al. (2016)
Surface Water | | Military^a^ | Anderson et al. (2016)
Frequency of detection (%) | 96.00 | Military^a^ | Anderson et al. (2016)
Median (ppb) | 0.320 | Military^a^ | Anderson et al. (2016)
Maximum (ppb) | 292 | Military^a^ | Anderson et al. (2016)
Groundwater | | Military^a^ | Anderson et al. (2016)
Frequency of detection (%) | 94.20 | Military^a^ | Anderson et al. (2016)
Median (ppb) | 0.820 | Military^a^ | Anderson et al. (2016)
Maximum (ppb) | 120 | Military^a^ | Anderson et al. (2016)
Water (ppb) | | NPL^b^ | ATSDR (2021)
Median | 0.25 | NPL^b^ | ATSDR (2021)
Geometric mean | 0.10 | NPL^b^ | ATSDR (2021)
Soil (ppb) | | NPL^b^ | ATSDR (2021)
Median | 1,175 | NPL^b^ | ATSDR (2021)
Geometric mean | 1,175 | NPL^b^ | ATSDR (2021)
Air (ppbv) | | NPL^b^ | ATSDR (2021)
Median | ND | NPL^b^ | ATSDR (2021)
Geometric mean | ND | NPL^b^ | ATSDR (2021)

a Samples collected between March and September 2014 from 10 active U.S. Air Force installations located throughout the United States, including Alaska, with a historic use of AFFFs; data originally reported as μg/kg.

b Concentrations found in ATSDR site documents; water and soil values represent data from two NPL sites.

#### Other Exposures

Schecter et al. (2012) collected 31 food samples from 5 grocery stores in Texas and analyzed them for persistent organic pollutants, including PFHxA. PFHxA was not detected in the samples. Chen et al. (2018) analyzed PFAS in a wide range of foods in Taiwan and detected PFHxA at geometric mean concentrations ranging from 0.03 ng/mL in milk to 1.58 ng/g in pork liver. Heo et al. (2014) analyzed a variety of foods and beverages in Korea for PFAS. PFHxA was detected in 8.1% of the fish and shellfish samples at a mean concentration of 0.037 ng/g; 8.1% of the dairy samples at a mean concentration of 0.051 ng/g; 9.5% of the beverage samples at a concentration of 0.187 ng/L; 20.5% of the fruit and vegetable samples at a mean concentration of 0.039 ng/g; and 51.3% of the meat samples at a mean concentration of 0.515 ng/g. Heo et al. (2014) also detected PFHxA in tap water in Korea at a mean concentration of 11.7 ng/L; PFHxA was not detected in bottled water. Pérez et al. (2014) analyzed PFAS in 283 food items (38 from Brazil, 35 from Saudi Arabia, 36 from Serbia, and 174 from Spain). PFHxA was detected in 6.0%, 21.3%, and 13.3% of the samples from Brazil, Saudi Arabia, and Spain, respectively. The mean concentrations of PFHxA were 270, 931, and 418 pg/g sample, respectively. The study did not find PFHxA in any of the Serbian samples. PFHxA was detected in microwave popcorn packaging materials at a range of 3.4 to 497 ng/g but was not detected in the corn or popcorn (Moreta and Tena, 2014).

Stahl et al. (2014) characterized PFAS in freshwater fish from 164 U.S. urban river sites and 157 near-shore Great Lakes sites. PFHxA was not detected in the fish from U.S. urban rivers but was detected in fish from 15% of the Great Lakes sites at a maximum concentration of 0.80 ng/g.

## 1.2 SUMMARY OF ASSESSMENT METHODS

This section summarizes the methods used for developing this assessment. A detailed description of these methods is provided in the PFAS Systematic Review Protocol for the PFDA, PFNA, PFHxA, PFHxS, and PFBA IRIS Assessments (see Appendix A and online (https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=345065)). The protocol includes additional problem formulation details, including the specific aims and key science issues identified for this assessment.

### 1.2.1 Literature Search and Screening

The detailed search approach, including the query strings and populations, exposures, comparators, and outcomes (PECO) criteria, are provided in Appendix A, Table 3-1. The results of the current literature search and screening efforts are documented in Section 2.1. Briefly, a literature search was first conducted in 2017 and regular yearly updates have been performed (the literature fully considered in the assessment was until April 2021). As described in the protocol, studies identified after peer review begins will only be considered for inclusion if they meet the PECO criteria and are expected to fundamentally alter the assessment’s conclusions (see Appendix A, Section 4.1).

The literature search queries the following databases (no literature was restricted by language):

- PubMed (National Library of Medicine (https://www.ncbi.nlm.nih.gov/pubmed/))
- Web of Science (Thomson Reuters (https://apps.webofknowledge.com/))
- Toxline (moved to PubMed (https://www.nlm.nih.gov/databases/download/toxlinesubset.html))
- TSCATS (Toxic Substances Control Act Test Submissions (https://cfpub.epa.gov/si/si_public_record_Report.cfm?dirEntryId=2855))

In addition, relevant literature not found through evidence base searching was identified by:

- Review of studies cited in any PFHxA PECO-relevant studies and published journal reviews; finalized or draft U.S. state, U.S. federal, and international assessments (e.g., the draft Agency for Toxic Substances and Disease Registry [ATSDR] assessment released publicly in 2018). In addition, studies included in ongoing IRIS PFAS assessments (PFHxS, PFNA, PFDA) were also scanned for any studies that met PFHxA PECO criteria.
- Review of studies submitted to federal regulatory agencies and brought to EPA’s attention. For example, studies submitted to EPA by the manufacturers in support of requirements under the Toxic Substances Control Act (TSCA).
- Identification of studies during screening for other PFAS. For example, epidemiological studies relevant to PFHxA sometimes were identified by searches focused on one of the other four PFAS currently being assessed by the IRIS Program.
- Other gray literature (i.e., primary studies not indexed in typical evidence bases, such as technical reports from government agencies or scientific research groups; unpublished laboratory studies conducted by industry; or working reports/white papers from research groups or committees) brought to EPA’s attention.

All literature, including literature search updates, is tracked in the EPA Health and Environmental Research Online (HERO) database (https://hero.epa.gov/hero/index.cfm/project/page/project_id/2628).^3^ The PECO criteria identify the evidence that addresses the specific aims of the assessment and focuses the literature screening, including study inclusion/exclusion (see Table 1-3).

Table 1-3 Populations, exposures, comparators, and outcomes (PECO) criteria

PECO element | Evidence
[underlined: P]opulations | Human: Any population and lifestage (occupational or general population, including children and other sensitive populations). The following study designs will be included: controlled exposure, cohort, case-control, and cross-sectional. (Note: Case reports and case series will be tracked as potential supplemental material.); Animal: Nonhuman mammalian animal species (whole organism) of any lifestage (including preconception, in utero, lactation, peripubertal, and adult stages).; Other: In vitro, in silico, or nonmammalian models of genotoxicity. (Note: Other in vitro, in silico, or nonmammalian models will be tracked as potential supplemental material.)
[underlined: E]xposures | Human: Studies providing quantitative estimates of PFAS exposure based on administered dose or concentration, biomonitoring data (e.g., urine, blood, or other specimens), environmental or occupational-setting measures (e.g., water levels or air concentrations, residential location and/or duration, job title, or work title). (Note: Studies that provide qualitative, but not quantitative, estimates of exposure will be tracked as supplemental material.); Animal: Oral or Inhalation studies including quantified exposure to a PFAS of interest based on administered dose, dietary level, or concentration. (Note: Nonoral and noninhalation studies will be tracked as potential supplemental material.) PFAS mixture studies are included if they employ an experimental arm that involves exposure to a single PFAS of interest. (Note: Other PFAS mixture studies are tracked as potential supplemental material.); Studies must address exposure to one or more of the following: PFHxA (CASRN 307-24-4), PFHxA sodium salt (CASRN 2923-26-4), PFHxA ammonium salt (CASRN 21615-47-4). [Note: although while these PFHxA is not metabolized or transformed in the body, there are precursor compounds known to be biotransformed to a PFAS of interest; for example, 6:2 fluorotelomer alcohol is metabolized to PFHxA and PFBA (Russell et al., 2015). Thus, studies of precursor PFAS that identify and quantify a PFAS of interest will be tracked as potential supplemental material (e.g., for ADME analyses or interpretations).]
[underlined: C]omparators | Human: A comparison or reference population exposed to lower levels (or no exposure/exposure below detection levels) or for shorter periods of time.; Animal: Includes comparisons to historical controls or a concurrent control group that is unexposed, exposed to vehicle-only or air-only exposures. (Note: Experiments including exposure to PFAS across different durations or exposure levels without including one of these control groups will be tracked as potential supplemental material [e.g., for evaluating key science issues; Section 2.4].)
[underlined: O]utcomes | All cancer and noncancer health outcomes. (Note: Other than genotoxicity studies, studies including only molecular endpoints [e.g., gene or protein changes; receptor binding or activation] or other nonphenotypic endpoints addressing the potential biological or chemical progression of events contributing toward toxic effects will be tracked as potential supplemental material [e.g., for evaluating key science issues; Section 2.4].)
PBPK models | Studies describing physiologically based pharmacokinetic (PBPK) and other PK models for PFDA (CASRN 335-76-2), PFDA ammonia salt (CASRN 3108-42-7), PFDA sodium salt (CASRN 3830-45-3), PFNA (CASRN 375-95-1), PFNA ammonium salt (CASRN 4149-60-4), PFNA sodium salt (CASRN 21049-39-8), PFHxA (CASRN 307-24-4), PFHxS (CASRN 355-46-4), PFHxS potassium salt (CASRN 3871-99-6), PFBA (CASRN 375-22-4), or PFBA ammonium salt (CASRN 10495-86-0).

ADME = absorption, distribution, metabolism, and excretion; PK = pharmacokinetic.

In addition to those studies meeting the PECO criteria and studies excluded as not relevant to the assessment, studies containing supplemental material potentially relevant to the specific aims of the assessment were inventoried during the literature screening process. Although these studies did not meet PECO criteria, they were not excluded. Rather, they were considered for use in addressing the identified key science issues (see Appendix A, Section 2.4) and other potential scientific uncertainties identified during assessment development but unanticipated at the time of protocol posting. Studies categorized as “potentially relevant supplemental material” included the following:

- In vivo mechanistic or mode-of-action studies, including non-PECO routes of exposure (e.g., intraperitoneal injection) and populations (e.g., nonmammalian models);
- In vitro and in silico models;
- Absorption, distribution, metabolism, and excretion (ADME) and pharmacokinetic (PK) studies (excluding models);.^4^
- Exposure assessment or characterization (no health outcome) studies;
- Human case reports or case-series studies; and

The literature was screened by two independent reviewers with a process for conflict resolution, first at the title and abstract level and subsequently the full-text level, using structured forms in DistillerSR (Evidence Partners (https://distillercer.com/products/distillersr-systematic-review-software/)). Literature inventories for studies meeting PECO criteria and studies tagged as “potentially relevant supplemental material” during screening were created to facilitate subsequent review of individual studies or sets of studies by topic-specific experts.

### 1.2.2 Evaluation of Individual Studies

The detailed approaches used for the evaluation of epidemiological and animal toxicological studies used in the PFHxA assessment are provided in the systematic review protocol (see Appendix A, Section 6). The general approach for evaluating health effect studies meeting PECO criteria is the same for epidemiological and animal toxicological studies although the specifics of applying the approach differ. Approaches for evaluating mechanistic evidence are described in detail in Appendix A, Section 6.5. The key concerns during the review of epidemiological and animal toxicological studies are potential bias (factors that affect the magnitude or direction of an effect in either direction) and insensitivity (factors that limit the ability of a study to detect a true effect; low sensitivity is a bias toward the null when an effect exists). Briefly, for epidemiology studies, evaluation of risk of bias and study sensitivity are conducted for the following domains: exposure measurement, outcome ascertainment, participant selection, potential confounding, analysis, study sensitivity, and selective reporting. The principles and framework used for evaluating epidemiology studies are based on the Cochrane Risk of Bias in Nonrandomized Studies of Interventions (ROBINS-I) but have been modified to address environmental and occupational exposures. For animal studies, risk of bias and study sensitivity are evaluated for the following domains: reporting quality, allocation, observational bias/blinding, confounding, selective reporting and attrition, chemical administration and characterization, exposure timing, frequency and duration, endpoint sensitivity and specificity, and results presentation. Details of the human epidemiology and animal toxicology methodology, including core and prompting questions as well as PFAS-specific criteria, are described in greater detail in Appendix A (see Appendix A, Sections 6.2 and 6.3, respectively).

In evaluating individual studies, two or more reviewers independently arrived at judgments about the reliability of the study results (reflected as study confidence determinations; see below) with regard to each outcome or outcome grouping of interest; thus, different judgments were possible for different outcomes within the same study. The results of these reviews were tracked within EPA’s version of the Health Assessment Workplace Collaborative (HAWC (https://hawcprd.epa.gov/assessment/100500070/)). To develop these judgments, each reviewer assigned a rating of good, adequate, deficient (or not reported, which generally carried the same functional interpretation as deficient), or critically deficient (see Appendix A, Section 6.1 for definitions) related to each evaluation domain representing the different characteristics of the study methods that were evaluated based on the criteria outlined in HAWC. Once all domains were evaluated, the identified strengths and limitations were collectively considered by the reviewers to reach a final study confidence classification:

- High confidence: No notable deficiencies or concerns were identified; the potential for bias is unlikely or minimal, and the study used sensitive methodology.
- Medium confidence: Possible deficiencies or concerns were noted, but the limitations are unlikely have a significant impact on the results.
- Low confidence: Deficiencies or concerns were noted, and the potential for bias or inadequate sensitivity could have a significant impact on the study results or their interpretation. Low confidence results were given less weight compared to high or medium confidence results during evidence synthesis and integration (see Section 1.2.4).
- Uninformative: Serious flaw(s) were identified that make the study results unusable. Uninformative studies were not considered further, except to highlight possible research gaps.

Using the HAWC (https://hawcprd.epa.gov/assessment/100500070/) platform (and conflict resolution by an additional reviewer, as needed), the reviewers reached a consensus judgment regarding each evaluation domain and overall (confidence) determination. The specific limitations identified during study evaluation were carried forward to inform the synthesis (see Section 1.2.4) within each body of evidence for a given health effect (i.e., study confidence determinations were not used to inform judgments in isolation).

### 1.2.3 Data Extraction

The detailed data extraction approach is provided in Appendix A, Section 8, and data extraction and content management is carried out using HAWC (https://hawcprd.epa.gov/assessment/100500070/) (see Appendix C). Data extraction elements that may be collected from epidemiological, controlled human exposure, animal toxicological, and in vitro studies are available in HAWC (https://hawcprd.epa.gov/assessment/100500070/). As described in the systematic review protocol (see Appendix A), not all studies that meet the PECO criteria go through data extraction: For example, studies evaluated as being uninformative are not used to inform assessment judgments and, therefore, do not undergo full data extraction.

All findings from informative studies are considered for extraction, regardless of statistical significance. The level of extraction for specific outcomes within a study might differ (e.g., ranging from a qualitative description to full extraction of dose response effect size information). For quality control, data extraction is performed by one member of the evaluation team and independently verified by at least one other member. Discrepancies in data extraction are resolved by discussion or consultation with a third member of the evaluation team.

### 1.2.4 Evidence Synthesis and Integration

For the purposes of this assessment, evidence synthesis and integration are considered distinct but related processes (see Appendix A, Sections 9 and 10 for full details). For each assessed health effect, the evidence syntheses provide a summary discussion of each body of evidence considered in the review that directly informs the integration across evidence that was used to draw an overall judgment for each health effect. The available human and animal evidence pertaining to the potential health effects were synthesized separately, with each synthesis resulting in a summary discussion of the available evidence that addresses considerations regarding causation adapted from Hill (1965). Briefly, the following aspects are considered for the available evidence: study confidence, consistency, strength (effect magnitude) and precision, biological gradient/dose response, coherence, mechanistic evidence related to biological plausibility, and natural experiments (applicable to human studies only). Detailed descriptions and application of these considerations are described in Appendix A, Section 9. Mechanistic evidence is also synthesized as necessary to help inform key decisions regarding the human and animal evidence; processes for synthesizing mechanistic information are covered in detail in Appendix A, Section 9.2.

The syntheses of the human and animal health effects evidence focus on describing aspects of the evidence that best inform causal interpretations, including the exposure context examined in the sets of available studies. The evidence synthesis is based primarily on studies of high and medium confidence. The systematic review protocol (see Appendix A) describes that, in certain instances (i.e., few or no studies with higher confidence are available), low confidence studies might be used to help evaluate consistency, or if the study designs of the low confidence studies address notable uncertainties in the set of high or medium confidence studies on a given health effect. If low confidence studies are used, a careful examination of the study evaluation and sensitivity with potential effects on the evidence synthesis conclusions will be included in the narrative. For the current assessment all studies meeting PECO criteria were used for evidence synthesis and included in the narrative. When possible, results across studies are compared using graphs and charts or other data visualization strategies. The synthesis of mechanistic information informs the integration of health effects evidence for both hazard identification (e.g., biological plausibility or coherence of the available human or animal evidence; inferences regarding human relevance, or the identification of susceptible populations and lifestages across the human and animal evidence) and dose-response evaluation (e.g., selection of benchmark response levels, selection of uncertainty factors). Evaluations of mechanistic information typically differ from evaluations of phenotypic evidence (e.g., from routine toxicological studies). This is primarily because mechanistic data evaluations consider the support for and involvement of specific events or sets of events within the context of a broader research question (e.g., support for a hypothesized mode of action; consistency with known biological processes), rather than evaluations of individual apical endpoints considered in relative isolation.

Following the synthesis of human and animal health effects data, and mechanistic data, integrated judgments are drawn across all lines of evidence for each assessed health effect. During evidence integration, a structured and documented process was used, as follows:

- Building from the separate syntheses of the human and animal evidence, the strength of the evidence from the available human and animal health effect studies was summarized in parallel, but separately, using a structured evaluation of an adapted set of considerations first introduced by Bradford Hill (Hill, 1965). This process is similar to that used by the Grading of Recommendations Assessment, Development, and Evaluation (GRADE) (Morgan et al., 2016; Guyatt et al., 2011; Schünemann et al., 2011), which arrives at an overall integration conclusion based on consideration of the body of evidence. These summaries incorporate the relevant mechanistic evidence (or mode of action [MOA] understanding) that informs the biological plausibility and coherence within the available human or animal health effect studies. The terms associated with the different strength of evidence judgments within evidence streams are robust, moderate, slight, indeterminate, and compelling evidence of no effect.
- The animal, human, and mechanistic evidence judgments are then combined to draw an overall judgment that incorporates inferences across evidence streams. Specifically, the inferences considered during this integration include the human relevance of the animal and mechanistic evidence, coherence across the separate bodies of evidence, and other important information (e.g., judgments regarding susceptibility). Note that without evidence to the contrary, the human relevance of animal findings is assumed. The final output is a summary judgment of the evidence base for each potential human health effect across evidence streams. The terms associated with these summary judgments are evidence demonstrates, evidence indicates (likely), evidence suggests, evidence inadequate, and strong evidence of no effect. The decision points within the structured evidence integration process are summarized in an evidence profile table for each considered health effect.
- In some instances (i.e., key science questions, coherence within and across biologically related outcomes, areas of uncertainty) the supplemental mechanistic information was reviewed and prioritized based on potential impact on assessment conclusions. For example, interpreting a pattern of changes or collection of findings from various health outcomes is strengthened by biological understanding (e.g., disruption of thyroid homeostasis through increased clearance of thyroid hormones during gestation may affect fetal growth and nervous system development) and progression to adverse outcomes and applicability in humans. Biological understanding, including strong mechanistic support for the chemical molecular interactions and conservation of those reactions and subsequent biological responses between species can increase certainty in strength of the evidence.

As discussed in the protocol (see Appendix A), the methods for evaluating the potential carcinogenicity of PFAS follow processes laid out in the EPA cancer guidelines (U.S. EPA, 2005) and that the judgments described here for different cancer types are used to inform the evidence integration narrative for carcinogenicity and selection of one of EPA’s standardized cancer descriptions. These are: (1) carcinogenic to humans, (2) likely to be carcinogenic to humans, (3) suggestive evidence of carcinogenic potential, (4) inadequate information to assess carcinogenic potential, or (5) not likely to be carcinogenic to humans. However, for PFHxA, data relevant to cancer were sparse and did not allow for such an evaluation (see Section 3.3).

### 1.2.5 Dose-Response Analysis

The details for the dose-response analysis completed for this assessment are in Appendix A, Section 11. Briefly, although procedures for dose-response assessments were developed for both noncancer and cancer health hazards, and for the oral route of exposure following exposure to PFHxA, the existing data for PFHxA only supported derivation of an oral reference dose (RfD) for noncancer hazards (see Appendix A, Section 11 for the health hazard conclusions necessary for deriving other values). An RfD is an estimate, with uncertainty spanning perhaps an order of magnitude, of an exposure to the human population (including susceptible subgroups) that is likely without an appreciable risk of deleterious health effects over a lifetime (U.S. EPA, 2002c). The derivation of a reference value like the RfD depends on the nature of the health hazard conclusions drawn during evidence integration. For noncancer outcomes, dose-response assessments were conducted for evidence integration judgments of evidence demonstrates and evidence indicates (likely). In general, toxicity values are not developed for noncancer hazards with evidence suggests conclusions (see Appendix A, Section 10.2 for exceptions).

Consistent with EPA practice, the PFHxA assessment applied a two-step approach for dose-response assessment that distinguishes analysis of the dose-response data in the range of observation from any inferences about responses at lower, environmentally relevant exposure levels (U.S. EPA, 2012a, 2005).

- Within the observed dose range, the preferred approach is to use dose-response modeling to incorporate as much of the data set as possible into the analysis, and considering guidance on modeling dose-response data, assessing model fit, selecting suitable models, and reporting modeling results [see the EPA Benchmark Dose Technical Guidance (U.S. EPA, 2012a)] as elaborated in Appendix A, Section 11. Thus, modeling to derive a POD attempted to include an exposure level near the lower end of the range of observation, without significant extrapolation to lower exposure levels.
- As derivation of cancer risk estimates and reference values nearly always involves extrapolation to exposures lower than the POD; the approaches to be applied in these assessments are described in more detail in Appendix A, Section 11.2.

When sufficient and appropriate human and laboratory animal data are available for the same outcome, human data are generally preferred for the dose-response assessment because use of human data eliminates the need to perform interspecies extrapolations. For reference values, this assessment will derive a candidate value from each suitable data set. Evaluation of these candidate values grouped within a given organ/system were used to derive a single organ/system-specific RfD (osRfD) for each organ/system under consideration from which a single overall reference value will be selected to cover all health outcomes across all organs/systems. Although this overall RfD represents the focus of the dose-response assessment, the osRfDs can be useful for subsequent cumulative risk assessments that consider the combined effect of multiple PFAS (or other agents) acting at a common organ/system. For noncancer toxicity values, uncertainties in these estimates are characterized and discussed. In addition, a less-than-lifetime, “subchronic” RfD was similarly estimated. Uncertainties in these toxicity values are transparently characterized and discussed. For dose-response purposes, EPA has developed a standard set of models (http://www.epa.gov/bmds) that can be applied to typical data sets, including those that are nonlinear. In situations where alternative models with significant biological support are available (e.g., pharmacodynamic models), those models are included as alternatives in the assessment(s) along with a discussion of the models’ strengths and uncertainties. EPA has developed guidance on modeling dose-response data, assessing model fit, selecting suitable models, and reporting modeling results [see the EPA Benchmark Dose Technical Guidance (U.S. EPA, 2012a)]. Additional judgment or alternative analyses are used if the procedure fails to yield reliable results; for example, if the fit is poor, modeling might be restricted to the lower doses, especially if competing toxicity at higher doses occurs. When alternative approaches fail or are not applicable, the NOAEL/LOAEL approach is used for POD estimation. For each modeled response, a POD from the observed data was estimated to mark the beginning of extrapolation to lower doses. The POD is an estimated dose (expressed in human-equivalent terms) near the lower end of the observed range without significant extrapolation to lower doses. The POD is used as the starting point for subsequent extrapolations and analyses. For noncancer effects, the POD is used in calculating the RfD.

2 The assessment applies to other non-linear isomers of PFHxA and related salts.

3 EPA’s Health and Environmental Research Online (HERO) database provides access to the scientific literature behind EPA science assessments. The database includes more than 3,000,000 scientific references and data from the peer-reviewed literature EPA uses to develop its risk assessments and related regulatory decisions.

4 Given the known importance of ADME data, this supplemental tagging was used as the starting point for a separate screening and review of PK data (see Appendix A, Section9.2 for details).