# REFERENCES

AACC (American Association for Clinical Chemistry). (1992). Clinical pathology testing recommendations for nonclinical toxicity and safety studies. Toxicol Pathol 20: 539–543.1296288
Chengelis, CP; Kirkpatrick, JB; Myers, NR; Shinohara, M; Stetson, PL; Sved, DW. (2009a). Comparison of the toxicokinetic behavior of perfluorohexanoic acid (PFHxA) and nonafluorobutane-1-sulfonic acid (PFBS) in cynomolgus monkeys and rats. Reprod Toxicol 27: 400–406. 10.1016/j.reprotox.2009.01.013.19429410
Chengelis, CP; Kirkpatrick, JB; Radovsky, A; Shinohara, M. (2009b). A 90-day repeated dose oral (gavage) toxicity study of perfluorohexanoic acid (PFHxA) in rats (with functional observational battery and motor activity determinations). Reprod Toxicol 27: 342–351. 10.1016/j.reprotox.2009.01.006.19429405
Crump, KS. (1995). Calculation of benchmark doses from continuous data. Risk Anal 15: 79–89. 10.1111/j.1539-6924.1995.tb00095.x.
Daikin Industries (Daikin Industries Limited). (2010). Oral (gavage) acute pharmacokinetic study of PFH ammonium salt (ammonium salt of perflourinated hexanoic acid) in mice. Osaka, Japan.
Dzierlenga, AL; Robinson, VG; Waidyanatha, S; Devito, MJ; Eifrid, MA; Gibbs, ST; Granville, CA; Blystone, CR. (2019). Toxicokinetics of perfluorohexanoic acid (PFHxA), perfluorooctanoic acid (PFOA) and perfluorodecanoic acid (PFDA) in male and female Hsd:Sprague dawley SD rats following intravenous or gavage administration. Xenobiotica 50: 1–11. 10.1080/00498254.2019.1683776.31625424
Gannon, SA; Johnson, T; Nabb, DL; Serex, TL; Buck, RC; Loveless, SE. (2011). Absorption, distribution, metabolism, and excretion of [1-^14^C]-perfluorohexanoate ([^14^C]-PFHx) in rats and mice. Toxicology 283: 55–62. 10.1016/j.tox.2011.02.004.21349313
Hall, AP; Elcombe, CR; Foster, JR; Harada, T; Kaufmann, W; Knippel, A; Küttler, K; Malarkey, DE; Maronpot, RR; Nishikawa, A; Nolte, T; Schulte, A; Strauss, V; York, MJ. (2012). Liver hypertrophy: a review of adaptive (adverse and non-adverse) changes--conclusions from the 3rd International ESTP Expert Workshop [Review]. Toxicol Pathol 40: 971–994. 10.1177/0192623312448935.22723046
Hill, AB. (1965). The environment and disease: Association or causation? Proc R Soc Med 58: 295–300.14283879
Iwabuchi, K; Senzaki, N; Mazawa, D; Sato, I; Hara, M; Ueda, F; Liu, W; Tsuda, S. (2017). Tissue toxicokinetics of perfluoro compounds with single and chronic low doses in male rats. J Toxicol Sci 42: 301–317. 10.2131/jts.42.301.28496036
Iwai, H; Hoberman, AM. (2014). Oral (Gavage) Combined Developmental and Perinatal/Postnatal Reproduction Toxicity Study of Ammonium Salt of Perfluorinated Hexanoic Acid in Mice. Int J Toxicol 33: 219–237. 10.1177/1091581814529449.24700568
Klaunig, JE; Shinohara, M; Iwai, H; Chengelis, CP; Kirkpatrick, JB; Wang, Z; Bruner, RH. (2015). Evaluation of the chronic toxicity and carcinogenicity of perfluorohexanoic acid (PFHxA) in Sprague-Dawley rats. Toxicol Pathol 43: 209–220. 10.1177/0192623314530532.25377447
Loveless, SE; Slezak, B; Serex, T; Lewis, J; Mukerji, P; O’Connor, JC; Donner, EM; Frame, S. R.; Korzeniowski, SH; Buck, RC. (2009). Toxicological evaluation of sodium perfluorohexanoate. Toxicology 264: 32–44. 10.1016/j.tox.2009.07.011.19632293
Luz, AL; Anderson, JK; Goodrum, P; Durda, J. (2019). Perfluorohexanoic acid toxicity, part I: Development of a chronic human health toxicity value for use in risk assessment. Regul Toxicol Pharmacol 103: 41–55. 10.1016/j.yrtph.2019.01.019.30639337
Nilsson, H; Kärrman, A; Rotander, A; van Bavel, B; Lindström, G; Westberg, H. (2013). Professional ski waxers’ exposure to PFAS and aerosol concentrations in gas phase and different particle size fractions. Environ Sci Process Impacts 15: 814–822. 10.1039/c3em30739e.23426585
NTP (National Toxicology Program). (2018). 28-day evaluation of the toxicity (C20613) of perfluorohexanoic acid (PFHxA) (307-24-4) on Harlan Sprague-Dawley rats exposed via gavage. Available online at https://tools.niehs.nih.gov/cebs3/views/?action=main.dataReview&bin_id=3879 (accessed
O’Connell, KE; Mikkola, AM; Stepanek, AM; Vernet, A; Hall, AD; Sun, CC; Yildirim, E; Staropoli, JF; Lee, JT; Brown, DE. (2015). Practical murine hematopathology: a comparative review and implications for research. Comp Med 65: 96–113.25926395
U.S. EPA (U.S. Environmental Protection Agency). (1991). Guidelines for developmental toxicity risk assessment. Fed Reg 56: 63798–63826.
U.S. EPA (U.S. Environmental Protection Agency). (2002). A review of the reference dose and reference concentration processes. (EPA630P02002F). Washington, DC. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2012). Benchmark dose technical guidance [EPA Report]. (EPA100R12001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/benchmark-dose-technical-guidance.
U.S. EPA (U.S. Environmental Protection Agency). (2015). Peer review handbook [EPA Report] (4th ed.). (EPA/100/B-15/001). Washington, DC: U.S. Environmental Protection Agency, Science Policy Council. https://www.epa.gov/osa/peer-review-handbook-4th-edition-2015.