# SUPPLEMENTAL INFORMATION

ABBREVIATIONS AND ACRONYMS
ADME: absorption, distribution, metabolism, and excretion
AFFF: aqueous film-forming foam
A:G: albumin:globulin ratio
AIC: Akaike’s information criterion
ALP: alkaline phosphatase
ALT: alanine aminotransferase
APTT: activated partial thromboplastin time
AST: aspartate aminotransferase
atm: atmosphere
ATSDR: Agency for Toxic Substances and Disease Registry
AUC: area under the curve
BMD: benchmark dose
BMDL: benchmark dose lower confidence limit
BMDS: Benchmark Dose Software
BMR: benchmark response
BUN: blood urea nitrogen
BW: body weight
C_max_: maximum concentration
CAR: constitutive androstane receptor
CASRN: Chemical Abstracts Service registry number
CBC: complete blood count
CHO: Chinese hamster ovary (cell line cells)
CI: confidence interval
CL: clearance
CL_A_: clearance in animals
CL_H_: clearance in humans
CPHEA: Center for Public Health and Environmental Assessment
CPN: chronic progressive nephropathy
DAF: dosimetric adjustment factor
DNA: deoxyribonucleic acid
DTXSID: DSSTox substance identifier
EPA: Environmental Protection Agency
FTOH: fluorotelomer alcohol
GD: gestation day
GGT: γ-glutamyl transferase
HAWC: Health Assessment Workplace Collaborative
HCT: hematocrit
HED: human equivalent dose
HERO: Health and Environmental Research Online
HGB: hemoglobin
HSA: human serum albumin
IQR: interquartile range
IRIS: Integrated Risk Information System
ISI: Influential Scientific Information
IUR: inhalation unit risk
i.v.: intravenous
LDH: lactate dehydrogenase
LLOQ: lower limit of quantitation
LOQ: limit of quantitation
LOAEL: lowest-observed-adverse-effect level
LOD: limit of detection
LOEC: lowest observed effect concentration
MCH: mean cell hemoglobin
MCHC: mean cell hemoglobin concentration
MCV: mean corpuscular volume
MOA: mode of action
MW: molecular weight
NCTR: National Center for Toxicological Research
NOAEL: no-observed-adverse-effect level
NPL: National Priorities List
NTP: National Toxicology Program
ORD: Office of Research and Development
OECD: Organisation for Economic Co-operation and Development
OSF: oral slope factor
osRfD: organ/system-specific oral reference dose
PBPK: physiologically based pharmacokinetic
PC: partition coefficient
PECO: populations, exposures, comparators, and outcomes
PFAA: perfluoroalkyl acids
PFAS: per- and polyfluoroalkyl substances
PFBA: perfluorobutanoic acid
PFBS: perfluorobutane sulfonate
PFCA: perfluorinated carboxylic acid
PFDA: perfluorodecanoic acid
PFHxA: perfluorohexanoic acid
PFHxS: perfluorohexane sulfonate
PFNA: perfluorononanoic acid
PFOA: perfluorooctanoic acid
PFOS: perfluorooctane sulfonate
PK: pharmacokinetic
PND: postnatal day
POD: point of departure
POD_HED_: human equivalent dose POD
PPAR: peroxisome proliferated activated receptor
PQAPP: programmatic quality assurance project plan
PT: prothrombin time
QA: quality assurance
QAPP: quality assurance project plan
QMP: quality management plan
RBC: red blood cells
RfC: reference concentration
RfD: oral reference dose
RNA: ribonucleic acid
ROS: reactive oxygen species
RXR: retinoid X receptor
SD: standard deviation
TP: total protein
TRI: Toxics Release Inventory
TSCATS: Toxic Substances Control Act Test Submissions
TSH: thyroid stimulating hormone
UF: uncertainty factor
UF_A_: interspecies uncertainty factor
UF_C_: composite uncertainty factor
UF_D_: evidence base deficiencies uncertainty factor
UF_H_: human variation uncertainty factor
UF_L_: LOAEL to NOAEL uncertainty factor
UF_S_: subchronic to chronic uncertainty factor
V _d_: volume of distribution