# APPENDIX E SUMMARY OF PUBLIC AND EXTERNAL PEER REVIEW COMMENTS AND EPA’S DISPOSITION

The Toxicological Review of Perfluorohexanoic Acid and Related Salts was released for public comment in February 2022. Public comments on the assessment were submitted to the U.S. Environmental Protection Agency (EPA) by April 4, 2022. The Toxicological Review has also undergone a formal external peer review in accordance with U.S. Environmental Protection Agency (EPA) guidance on peer review (U.S. EPA, 2015). A public, external peer-review meeting was held May 16 and 17, 2022, which included another opportunity for public comment. The external peer reviewers were tasked with providing written answers to general questions on the overall assessment approach, key conclusions, and areas of scientific controversy or uncertainty. A summary of comments made by the external peer reviewers and public commenters, as well as EPA’s responses to these comments, are arranged by charge question. In many cases, the comments of the individual reviewers have been synthesized and paraphrased for brevity (please consult the final peer review report for the full text of the panel’s comments: Peer Review Report (https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=352767#:~:text=In%20February%202022%2C%20the%20IRIS,ERG%2C%20a%20contractor%20to%20EPA.)). External Peer Reviewers were asked to prioritize their comments to indicate their relative importance as follows. The prioritization instructions are duplicated below from the IRIS PFHxA charge questions to the peer reviewers, which can be found in the public EPA docket (EPA-HQ-ORD-2021-0561 (https://www.regulations.gov/docket/EPA-HQ-ORD-2021-0561)):

- Tier 1: Necessary Revisions – Use this category for any revisions you believe are necessary to adequately support and substantiate the analyses or scientific basis for the assessment conclusions, or to improve the clarity of the presentation in the PFHxA Toxicological Review.
- Tier 2: Suggested Revisions – Use this category for any revisions you encourage EPA to implement to strengthen the analyses or scientific basis for the assessment conclusions, or to improve the clarity of the presentation in the PFHxA Toxicological Review.
- Tier 3: Future Considerations – Use this category for any advice you have for scientific exploration that might inform future work. While these recommendations are generally outside the immediate scope or needs of the PFHxA Toxicological Review, they could inform future reviews or research efforts.

Appendix E lists all Tier 1 recommendations and Tier 2 Suggestions from the external peer reviewers organized by charge question. For Tier 3 Considerations, please refer to the external peer review report linked above. Where public comments were made on topics raised by the external peer reviewers, they are noted along with the external peer review comments. All Tier 1 recommendations were implemented in this revised assessment, either through revision or addition to the peer reviewed analyses or text. Tier 2 suggestions were considered in light of the extent to which those suggestions would impact the conclusions or quantitative analyses of the assessment, consistency across committee in raising the suggestion, and the level of effort to implement. For this assessment, all Tier 2 suggestions deemed to be impactful to the toxicity value conclusions were implemented in this revised assessment. Additional public comments not raised by the peer reviewers are included in a separate section at the end of each charge question section. In many cases, the public comments have been synthesized and paraphrased for brevity, both in this Appendix and in the summary, document provided as a courtesy to the external peer review panel. Please see docket (EPA-HQ-ORD-2021-0561 (https://www.regulations.gov/docket/EPA-HQ-ORD-2021-0561)) for both this summary document and the full text of the submitted public comments.

External peer reviewer and public comments regarding requests for additions of clarifying text or editorial or grammatical corrections have been made throughout the assessment as appropriate; these comments and responses have not been tracked in this Appendix.

## E.1 CHARGE QUESTIONS 1 AND 2 – SYSTEMATIC REVIEW AND DOCUMENTATION

1) The Toxicological Review for PFHxA describes and applies a systematic review protocol for identifying and screening pertinent studies. The protocol is described in brief detail in Section 1.2.1 (Literature Searching and Screening) and in full detail in Appendix A (Systematic Review Protocol for the PFAS IRIS Assessments). Please comment on whether the search strategy and screening criteria for PFHxA literature are clearly described. If applicable, please identify additional peer-reviewed studies of PFHxA that the assessment should incorporate^1^.
2) The Toxicological Review provides an overview of individual study evaluations and the results of those evaluations are made available in the Health Assessment Workplace Collaborative linked HAWC (https://www.epa.gov/risk/health-assessment-workspace-collaborative-hawc). Note that a “HAWC FAQ for assessment readers” document is available (scroll to the bottom of the page, and the document is available for download under “attachments”) and is intended to help the reviewer navigate this on-line resource. Data from studies considered informative to the assessment are synthesized in the relevant health effect-specific sections, and study data are available in HAWC.
  a. Please comment on whether the study confidence conclusions for the PFHxA studies are scientifically justified and clearly described, considering the important methodological features of the assessed outcomes. Please indicate any study confidence conclusions that are not justified and explain any alternative study evaluation decisions.
  b. Results from individual PFHxA studies are presented and synthesized in the health system specific sections. Please comment on whether the presentation and analysis of study results are clear, appropriate, and effective to allow for scientifically supported syntheses of the findings across sets of studies.

### E.1.1 External Peer Reviewer Comments on Systematic Review and Documentation

For charge question 1, “all reviewers agreed that the search strategy and criteria were appropriate and clearly described. One reviewer noted how inherently challenging it is to identify pertinent studies with the increasing interest in PFAS, which has led to an increasing rate of new publications. Several reviewers provided references to additional studies for EPA’s consideration.” For charge question 2, “six of the seven reviewers agreed that the confidence conclusions for the PFHxA studies were scientifically justified and clearly described. For example, one reviewer noted that the visual presentation of the evaluation results for the animal studies was very effective and found the use of interactive graphics to be very convenient.” The seventh reviewer provided a Tier 1 Recommendation to improve the presentation. The report also noted that “reviewers generally found the presentation and analysis of the study results as they appear in the health system-specific sections to be clear but recommended several Tier 1 and Tier 2 revisions to improve the clarity and accuracy of the presentation.” These comments are described below.

#### Tier 1 Recommendations

[underlined: Comment:] EPA should add text describing the major reasons for excluding the 194 articles during the screening process, as shown in Figure 2-1.

[underlined: EPA Response:] Studies are excluded if they do not meet all PECO criteria. During screening, most studies are excluded because they do not meet any or only meet a few of the PECO criteria. Thus, a single screened out study typically has multiple reasons for exclusion which is unwieldy to document, especially at the title and abstract level when screening may be needed for thousands of studies. Some of the studies that did not meet all PECO criteria were considered to have potentially relevant supplemental information. In these instances, tags were added (if not already present) to indicate the type(s) of potentially relevant supplemental information and can be visualized using the interactive HAWC literature tag tree available by clicking the following link: https://hawc.epa.gov/lit/assessment/100500070/references/visualization/. A sentence was added to Section 2.1 to clarify that excluded studies “did not meet the PECO and did not contain potentially relevant supplemental information.”

[underlined: Comment:] EPA should add several sentences to Section 1 that describe the in-press paper EHP (DOI 10.1289/EHP 10343) shown in EPA’s slides during the May 16, 2022, peer review. In particular, the reviewer noted that the evidence maps illustrating how EPA is going to synthesize evidence across the PFAS compounds would be a good addition to the text.

[underlined: EPA Response:] A brief description of the EHP paper was added to Section 4.1, before Table 4.1 that provides an overview of health effects that have been described for several other recent EPA PFAS assessments.

[underlined: Comment:] EPA should update HAWC for PFHxA to include assessments/evaluations of recent studies that will be considered in finalizing this Toxicological Review.

[underlined: EPA Response:] The date of the last literature search used for the Toxicological Review (April 2022) was added to Section 2.1 and in HAWC. Updates to the literature incorporated into the assessment are reflected in a separate document posted to the docket (“EPA-HQ-ORD-2021-0561-0019 (https://www.regulations.gov/document/EPA-HQ-ORD-2021-0561-0019)”) and provided to the peer reviewers. This document describes the consideration of the studies deemed relevant based on the methods laid out in the protocol and documents the justification for the subset of those incorporated into the revised assessment.

[underlined: Comment:] EPA should expand the discussion in Section 1.2.4 (or an additional section) on the use of low confidence studies to support mechanistic evidence when the mechanistic evidence is used across health effects.

[underlined: EPA Response:] Additional text was added to Section 1.2.4 on the use of low confidence studies to support coherence of mechanistic findings.

[underlined: Comment:] In Table 3-28, EPA should include the results of two high confidence studies that did not report significant changes to histopathology as the inclusion of only the one study with significant effects is being highlighted, paints an incomplete picture.

[underlined: EPA Response:] The thyroid histopathology data from NTP (2018) and Klaunig et al. (2015) were added to the relevant table in Section 3.2.5.

[underlined: Comment:] To clarify how decisions were made for each health endpoint, EPA should add a brief section on the considerations used in evaluating study quality and summarize the basis for assignments. Inclusion of this information solely within the HAWC template does not enable the reader to readily identify the basis for judgments about individual studies or the rationale behind the assignments.

[underlined: EPA Response:] Additional text was added to Section 1.2.2 that describes the study evaluation for the epidemiology and animal toxicology studies. Readers are referred to the Protocol for a detailed description of the study evaluation approach for both human epidemiology and animal toxicology studies (Appendix A, Sections 6.2 and 6.3, respectively).

[underlined: Comment:] EPA should enumerate the adaptations made to the structured evaluation considerations first introduced by Hill (1965).

[underlined: EPA Response:] Additional text was added to Section 1.2.4 that describes the specific modified Hill considerations that are applied for IRIS Assessments. Readers are referred to the Protocol (Appendix A, Section 9) for detailed descriptions of the considerations and the application during evidence synthesis and integration.

#### Tier 2 Suggestions

[underlined: Comment:] EPA should summarize key points for other EPA PFAS reviews so a user of the IRIS materials could see similarities and differences in this family of related chemicals. The reviewer noted that users of the IRIS documents will usually be addressing mixtures of these compounds in the field, therefore, a common summary in one place would help the user community coordinate the information.

[underlined: EPA Response:] Table 4-1 has been added to the assessment (see Section 4.1) to facilitate comparisons of toxicity hazard conclusions across EPA PFAS assessments.

[underlined: Comment:] In the systematic review protocol in Appendix A (Table 5-2), EPA should clarify why dam health (e.g., weight gain, food consumption) was only considered in “Developmental” and not in “Reproductive” or tied to the specific effect on dam health observed (e.g., weight gain as an endpoint).

[underlined: EPA Response:] Although effects on dam body weight were not specified as endpoint grouping categories for animal toxicology studies in the PFAS protocol (Appendix A, Table 5-2), these data were synthesized in the female reproductive health effects section (Section 3.2.7) as well as considered when interpreting the developmental health effects (Section 3.2.2) in the toxicological review. As stated on pg 5–3, lines 7–11, the endpoint groupings outlined in Tables 5-1 and 5-2: “are meant to serve as a starting place for consistency in presentation and analysis across studies and assessments, although assessment-specific deviations are possible (e.g., depending on the assessment-specific database of endpoints in the available studies or PFAS-specific understanding of mechanistic relationships across outcomes).”

[underlined: Comment:] EPA should consider including a list of documents relevant to PFHxA risk characterization that have been developed by state and international regulatory agencies in the literature searches and in resulting databases.

[underlined: EPA Response:] State and international regulatory agency documents related to PFAS are included in EPA literature searches and managed in HERO. EPA does not generally include a description of non-EPA judgements in EPA assessments but does use these documents as a resource for the identification of key science issues and potentially relevant studies that may have been missed by a database search at early stages of draft assessment development.

[underlined: Comment:] EPA should consider incorporating recently published studies in the Toxicological Review.

[underlined: EPA Response:] Additional studies were considered for incorporation into the toxicological review for PFHxA. Of the studies that were considered, a subset was prioritized for inclusion depending on whether they were expected to inform critical data gaps. Additional details regarding the studies that were prioritized for inclusion can be found in the docket (see EPA-HQ-ORD-2021-0561-0019 (https://www.regulations.gov/document/EPA-HQ-ORD-2021-0561-0019)).

[underlined: Comment:] For increased transparency and ease of reference, EPA should consider adding the HAWC animal toxicity study evaluation figure to the main document in addition to including it in the HAWC.

[underlined: EPA Response:] A copy of animal study evaluation heat map in HAWC has been added to Section 2.2 of the toxicological review.

[underlined: Comment:] For hepatic effects (Table 3-11), EPA should consider several revisions: 1) Consider additional tables and/or figures to help readers visualize the coherence of liver histopathology with liver weight effects since these results are only presented in separate tables in the document; 2) reconsider whether to include decreases in bilirubin amongst the serum biomarkers of hepatic injury cited in Table 3-11 based on the Loveless et al. (2009) and Hall et al. (2012) studies; and 3) in characterizing the strength of this evidence, reconfirm that the significant variability of responses across studies and sexes was considered and weighed, as well as the magnitude (frequently modest) and direction of change in the cases where there was a change in one of the serum enzyme biomarkers (in many cases there were decreases).

[underlined: EPA Response:] The hepatic evidence is discussed considering the Hall et al. (2012) criteria in Section 3.2.1 under the subheading “Considerations for Potentially Adaptive Versus Adverse Responses”. The criteria for considering the adversity of hepatic effects according to Hall is listed and a summary of the hepatic findings are included below the Hall criteria where decreases in bilirubin, globulin, and total protein are also summarized. The serum enzyme findings were clarified to indicate the magnitude of change and a statement summarizing the different clearance rates of PFHxA in rats (faster clearance in females than males) may underlie sex-specific differences.

[underlined: Comment:] For developmental effects, EPA should consider revisions to further characterize the mouse dose-response for decreases in postnatal body weight.

[underlined: EPA Response:] Additional text was added to Section 3.2.2 clarify that the data from the mouse study by Iwai and Hoberman (2014) represent two separate experimental cohorts with overlapping dose ranges. Although, in general, similar effects are observed across the two cohorts there is some variability in the dose response pattern which, as now discussed in the assessment, could be explained by normal variation across the control body weights in two experiments or a survivor bias at the higher doses (e.g., higher mortality among low body weight pups in the higher doses).

[underlined: Comment:] For hematopoietic effects, EPA should consider revisions to: 1) add a table and/or figure to help readers visualize the coherence of these effects since these results are presented in separate figures and tables in the document; and 2) add information on the results of several chronic studies which are an important exception to the cited “consistent treatment related effect on platelet levels.”

[underlined: EPA Response:] Findings from the chronic study are made available in the draft on hematological effects for all hematological findings that are described throughout Section 3.2.4. The reviewer may have been referring to time points beyond 52 weeks of age that were not considered based on as quantitative measures of hematology measures beyond 52 weeks may be complicated by natural diseases occurring in rodents and test variability leading to decreased sensitivity and increasing variability with the results (AACC, 1992). The collection of blood findings are summarized in a visualization available in HAWC (linked here: https://hawc.epa.gov/summary/data-pivot/assessment/100500070/pfhxa-animal-toxicology-hematology-effects-eryth/) as well as in the evidence integration section to help readers understand the coherence of effects.

### E.1.2 Public Comments on Systematic Review and Documentation

[underlined: Comment:] Several public commenters noted a lack of clarity regarding the literature search and screening results, including inconsistencies in the screening results shown in HERO, HAWC, and within the Toxicological Review, lack of clarity on how potentially relevant supplemental information and newly identified studies would be incorporated in the Toxicological Review. Some public commenters provided specific references or additional data that were not included in the public comment draft of the PFHxA Toxicological Review.

[underlined: EPA Response:] EPA has taken several steps to clarify the literature search and screening results for PFHxA that are now resolved and are available for viewing in HAWC and are available using the following link: https://hawc.epa.gov/lit/assessment/100500070/references/visualization/

## E.2 CHARGE QUESTION 3: NONCANCER HAZARD IDENTIFICATION

3) For each health effect considered in the assessment and outlined below, please comment on whether the available data have been clearly and appropriately synthesized to describe the strengths and limitations. For each, please also comment on whether the weight-of-evidence decisions for hazard identification are scientifically justified and clearly described.
  a. For hepatic effects, the Toxicological Review concludes the available evidence indicates PFHxA likely causes hepatic effects in humans under relevant exposure circumstances. This conclusion is based on studies of rats showing increased liver weight, hepatocellular hypertrophy, increased serum enzymes, and decreased serum globulins. The hepatic findings for PFHxA were similar for other PFAS and determined to be adverse and relevant to humans.
    i) Additional considerations influenced the hepatic effects hazard identification decisions. Appendix A (Systematic Review Protocol for the PFAS IRIS Assessments) outlines the human relevance of hepatic effects in animals that involve PPARα receptors as a key science issue. To the extent supported by the PFHxA literature (and to a lesser extent, literature for other PFAS), the Toxicological Review evaluates the evidence relevant to the potential involvement of PPARα and non-PPARα pathways with respect to the reported hepatic effects. The Toxicological Review ultimately concludes evidence from in vivo (including genetic mouse models) and in vitro studies support a potential role for multiple pathways operant in the induction of hepatic effects from PFHxA exposure, but those pathways cannot be specifically determined. Please comment on whether the conclusions regarding the available animal and mechanistic studies are scientifically justified and clearly described. The hepatic findings for PFHxA were similar for other PFAS and determined to be adverse and relevant to humans.
  b. For developmental effects, the Toxicological Review concludes the available evidence indicates PFHxA likely causes developmental effects in humans under relevant exposure circumstances. This judgment is based primarily on gestational exposure experiments in mice, with supportive findings in rats exposed throughout gestation and lactation, showing increased perinatal mortality, decreased offspring body weight, and delayed eye opening. These effects are similar to those observed for other PFAS following developmental exposure and were determined to be adverse and relevant to humans.
  c. For hematopoietic effects, the Toxicological Review concludes the available evidence indicates PFHxA likely causes hematopoietic effects in humans under relevant exposure circumstances. This judgment is based on consistent findings, including decreased red blood cells [RBCs], hematocrit, and hemoglobin, across study designs that, when interpreted together, signifies PFHxA-related hematological effects such as anemia. These findings were determined to be adverse and relevant to humans.
  d. For endocrine effects, the Toxicological Review concludes the available evidence suggests, but is not sufficient to infer, that PFHxA may cause endocrine effects in humans under relevant exposure circumstances. This conclusion is based on some evidence of thyroid effects based on hormone and histopathological changes in two rat studies; however, the data is limited, lacking consistency across studies, and histopathological changes may be explained by non-thyroid related effects
  e. For all other potential health effects (i.e., renal, male and female reproductive, immune, and nervous system), the Toxicological Review concluded the available evidence is inadequate to assess whether PFHxA may cause effects in humans under relevant exposure circumstances. In general, these conclusions were driven by sparse evidence bases or data that were largely null.

### E.2.1 External Peer Review Comments on Hepatic Effects

All seven reviewers were in agreement with the draft Toxicological Review that the data has been “clearly and appropriately synthesized in order to describe the strengths and limitations of the data” and that the weight-of evidence decisions used for hazard identification were “scientifically justified and clearly described” for the hepatic effects from PFHxA. One reviewer also noted, “importantly, recommendations of the Hall et al. (2012) paper were considered by the EPA in assessing the adversity of observed hepatic effects,” while another reviewer applauded inclusion of this discussion and outcome stating that it was, “a compelling narrative, which compares point by point the PFHxA responses against this guide concludes that these responses are adverse, human relevant and of concern for such biological effects of necrosis”. One reviewer noted that, “the IRIS draft report included a section that discussed “evidence from other PFAS” …was especially important for interpreting the PFHxA results and by structural analogy that PFHxA would also work via both PPAR alpha and non PPAR alpha response pathways. These comparisons showed that the involvement of other non PPAR alpha receptors in the response to PFAS and by structural relationship relevance for PFHxA.” Several Tier 2 Suggestions are described below.

#### Tier 1 Recommendations

Reviewers had no Tier 1 recommendations.

#### Tier 2 Suggestions

[underlined: Comment:] To improve clarity, EPA should revise the text (page 2–3) stating, “All outcomes rated low confidence or higher were used for evidence synthesis and integration.” The reviewer commented that it may be unclear how this statement can be consistent with the statement on page 1-12 that “no low confidence studies were used in the evidence syntheses for PFHxA included in the narrative,” since low confidence studies may presumably have outcomes that would also be rated as low confidence, which might be assumed to be included in evidence synthesis and integration based on the first sentence cited.

[underlined: EPA Response:] The text in Section 1.2.4 has been edited. It now correctly states that “all studies meeting PECO criteria were used for evidence synthesis and included in the narrative.”

[underlined: Comment:] EPA should consider utilizing information on other PFAS compounds (e.g., PFBA) to supplement and bolster the evidence consistent with the adversity of PFHxA-induced hepatic effects.

[underlined: EPA Response:] In addition to the text in the Hepatic outcome Section (Section 3.2.1), the assessment now includes an additional section in Section 4 including narrative description and table summary (Table 4-1) comparing the hazard conclusions across published EPA PFAS Assessments.

[underlined: Comment:] A reviewer noted an inconsistency in discussions of necrosis in rats and suggested that EPA revise the wording to be consistent.

[underlined: EPA Response:] The text has been edited to correct the inconsistency. The synthesis in Section 3.2.1 now correctly states that necrosis was observed in females but not males.

[underlined: Comment:] In the “Evidence from other PFAS” section, EPA should consider emphasizing that the observations of PPARα independent and dependent pathways from the four other PFAS are consistent for both short-chain (e.g., PFBA) and long-chain (e.g., PFNA) substances, increasing the plausibility that it also applies to PFHxA.

[underlined: EPA Response:] Although there is no evidence specifically challenging the role of PPARα in PFHxA-mediated hepatotoxicity, based on PFHxA structural similarity with other PFAS, most notably PFBA, it is reasonable to infer that PFHxA exposure in genetic mouse model systems would elicit similar effects as structurally similar PFAS. Therefore, text was added to Section 3.2.1 specifically stating evidence from structurally similar PFAS, including PFBA, suggest PPARα independent and dependent pathways also apply to PFHxA (Evidence from other PFAS subheading).

[underlined: Comment:] A reviewer commented that while the interpretation of both epidemiologic studies is reasonable, it is not clear why the potential for confounding is considered to be so substantial without some indication of the rationale for expecting that serum PFHxA levels are associated with the confounding factors. EPA should consider including stronger reasoning as to why such confounding would be expected. This comment applies to all health effect sections.

[underlined: EPA Response:] Text was added to human studies sections to further explain the concerns for confounding. While not explicitly described in each section, studies were rated as “critically deficient” for confounding and “uninformative” overall when there was no consideration (e.g., adjustment, exclusion, stratification) for potential confounders in heterogeneous populations. There is particular concern with PFAS that lack of adjustment for age and sex would lead to substantial bias given that these variables are associated with both PFAS exposure and most of the outcomes of interest.

### E.2.2 Public Comments on Hepatic Effects

[underlined: Comment:] Public comments on EPA’s conclusions made regarding hepatic effects in the toxicological review were mixed. One commenter agreed with the overall conclusion and supported EPA’s position that the hepatic effects are adverse and relevant to humans. In contrast, two public commenters expressed concerns about the human relevance of mechanistic support for hepatic effects via PPARα mediated pathways and the adversity of the observed hepatic effects in animal toxicity studies. Based on these concerns the commenters felt that the hepatic effects should be considered to be inadequate to assess whether PFHxA may cause hepatic effects in humans.

[underlined: EPA Response:] The conclusions in the draft Toxicological Review regarding hepatic effects were supported by the external peer review committee who provided tier 2 recommendations that were addressed in the assessment. The text includes evidence from other PFAS (short and long chain) in models challenging the role of PPARα in PFHxA-mediated hepatotoxicity indicating roles for PPARα dependent and independent pathways. The evidence is considered relevant to PFHxA considering the PFAS evaluated are of similar carbon chain length and structure. The conclusions were also supported by supplemental mechanistic evidence indicating the human PPARα binds and is activated by PFHxA at similar or lower concentrations than rodent PPARα. Further, evaluation of the available evidence was considered in the context of the Hall et al. (2012) criteria. While PFHxA exposure does not clearly lead to cancer there is evidence for hepatic toxicity rather than adaptation in rodents. The overall evidence is considered to be adverse and relevant to humans.

### E.2.3 External Peer Review Comments on Developmental Effects

All seven reviewers agreed with the assessment conclusions for developmental effects. One reviewer stated that, “The integration of available animal data, based on two high quality animal studies (with three experiments) and on plausibility for human relevance, supports the finding that PFHxA likely causes developmental effects in humans.” Another reviewer stated that “The Agency’s logic was clear and transparent, and their conclusions scientifically justified.” Several Tier 2 Suggestions are described below.

#### Tier 1 Recommendations

Reviewers had no Tier 1 recommendations.

#### Tier 2 Suggestions

[underlined: Comment:] EPA should consider improving the discussion of human relevance such as by adding information on the conserved biological processes or similarities in anatomy and physiology between rodents and humans that EPA considers relevant to the observed developmental effects, or whether rodents (particularly the mouse) have been shown to be good laboratory animal models for assessing potential human developmental effects.

[underlined: EPA Response:] The text has been edited in Section 3.2.2. “These findings are interpreted as relevant to humans in the absence of evidence to the contrary. This assumption is based on Guidelines for Developmental Toxicity Risk Assessment (U.S. EPA, 1991).” The assumption in the EPA Guidelines is based on data for known developmental toxicants which have shown that animal models are largely predictive of effects in humans.

### E.2.4 Public Comments on Developmental Effects

[underlined: Comment:] Public comments on EPA’s conclusions made regarding developmental effects in the draft toxicological review were mixed. One commenter agreed with the overall conclusion that PFHxA is likely to cause developmental effects in humans. In contrast, two public commenters expressed concerns about strength of the evidence base to support the conclusion, specifically the small evidence base (two animal toxicology studies) to inform developmental effects of PFHxA. Concern about the adversity of decreased offspring body weight and these effects may be secondary to maternal toxicity rather than a direct effect on development. Based on these concerns these commenters felt that EPA should reconsider the conclusions for this health effect.

[underlined: EPA Response:] The conclusions in the draft Toxicological Review regarding developmental effects were supported by the external peer review committee and retained in the revised assessment. The evidence integration narrative in 3.2.2 discusses the potential impacts of maternal toxicity on the interpretation of the animal evidence based and the rationale for why maternal toxicity was not expected to be a primary driver of the observed developmental effects.

### E.2.5 External Peer Review Comments on Hematopoietic Effects

Six of seven reviewers supported the overall conclusions of the hematopoietic effects section, while one reviewer recommended clarifying, and possibly strengthening, the animal evidence synthesis judgment (see Tier 1 Recommendation below). One reviewer commented that “the weight-of evidence decisions used for hazard identification were scientifically justified and clearly described and that when the rat studies are examined as a collective of study results, they provide compelling evidence for PFHxA causing macrocytic anemia (low hemoglobin and large RBC) and could be expected to cause serious harm in humans”. While one reviewer stated that “the findings are consistent with similar effects for multiple other PFAS and are reasonably determined to be adverse and relevant to humans” a separate reviewer suggested “EPA should consider adding additional information supporting the human relevance of hematopoietic effects observed in rats.” (see Tier 2 Suggestion below).

#### Tier 1 Recommendations

[underlined: Comment:] EPA should clarify why the animal evidence is “moderate” rather than “robust” given that all four animal studies were assessed high confidence and there was agreement across study findings and doses. The reviewer noted that this clarification would provide context for what drives the “moderate” decision, and it will help to align with the conclusion that “the currently available evidence indicates that PFHxA likely causes hematopoietic effects in humans.”

[underlined: EPA Response:] Based on external peer review input and further review of the evidence, it was determined that there is robust animal evidence for hematopoietic effects and the judgment was changed in the assessment. This did not change the overall evidence integration judgement based on based on identification of only one uninformative human study and uncertainty around the human relevance of the rodent findings. Specifically, rodent hematological parameters differ from humas by smaller erythrocytes, higher percentage of circulating reticulocytes (or polychromasia), physiologic splenic hematopoiesis and iron storage, and more numerous and shorter-lived erythrocytes and platelets (O’Connell et al., 2015). These differences could explain the possible regenerative response in the spleen and bone and the increase in reticulocytes (i.e., erythrogenesis and RBC turnover more rapid in rodent vs. human). Therefore, the currently available evidence indicates that PFHxA likely causes hematopoietic effects in humans given sufficient exposure conditions.

#### Tier 2 Suggestions

[underlined: Comment:] EPA should consider improving the discussion of human relevance such as by adding information on the conserved biological processes between rats and humans that EPA considers relevant to the observed hematopoietic effects, or whether rodents (particularly the mouse) have been shown to be good laboratory animal models for assessing potential human hematopoietic effects.

[underlined: EPA Response:] A discussion of the human relevance of hematopoietic effects (Section 3.1.4) in rodents was added to the integration narrative. This additional discussion included background information on the rodent model strain and origin (all animal models were obtained from the same outbred population and supplier). Additional text also included a comparison between murine and human hematological parameters. Specifically, rodent hematological parameters differ from humas by smaller erythrocytes, higher percentage of circulating reticulocytes (or polychromasia), physiologic splenic hematopoiesis and iron storage, and more numerous and shorter-lived erythrocytes and platelets (O’Connell et al., 2015). These differences could explain the possible regenerative response in the spleen and bone and the increase in reticulocytes (i.e., erythrogenesis and RBC turnover more rapid in rodent vs. human).

### E.2.6 Public Comments on Hematopoietic Effects

[underlined: Comment:] There were mixed responses to the conclusions made regarding hematopoietic effects in the toxicological review. One commenter agreed with the overall conclusion and recommended additional text be drafted discussing similarity of effects observed across related PFAS. In contrast, two public commenters expressed concerns about strength of the evidence base to support the conclusion, specifically citing the lack of mechanistic and informative human data and questioning the adversity and biological significance of findings in animals. Based on these concerns these commenters felt that EPA should reconsider the conclusions for this health effect.

[underlined: EPA Response:] EPA added additional discussion on the human relevance of the hematologic effects (Section 3.2.4) observed in rodents and determined that, while there is robust evidence available from the animal data, there is indeterminate human evidence and some residual uncertainty around the human relevance of the observed effects; therefore, the evidence indicates PFHxA likely causes hematopoietic effects, a judgement that was supported by external peer review. Please see the responses above to peer reviewer comments.

### E.2.7 External Peer Review Comments on Endocrine Effects

There were mixed responses from the committee on the conclusions made regarding endocrine effects in the toxicological review. Three reviewers agreed with the conclusion that “the currently available evidence suggests, but is not sufficient to infer, that PFHxA might cause endocrine effects in humans under relevant exposure circumstances.” One reviewer stated, “Overall, the critical available data on endocrine effects are clearly and appropriately synthesized to describe the strengths and limitations. In this reviewer’s opinion, the weight-of-evidence decision for endocrine effects is scientifically justified.” In contrast, three reviewers recommended EPA reconsider the conclusion on endocrine effects and their specifics comments are outlined in the Tier 1 Recommendations below. One reviewer did not comment on the overall conclusions or provide other specific recommendations or suggestions in response to this charge question.

#### Tier 1 Recommendations

[underlined: Comment:] Two reviewers recommended that EPA strengthen the evidence integration judgment and conclude that the available evidence indicates that PFHxA exposure is likely to cause thyroid toxicity in humans given relevant exposure circumstances, primarily based on short-term studies in rats reporting a consistent and coherent pattern of effects on thyroid hormones following PFHxA exposure, but also drawing from the consistency of effects when considering evidence from structurally related PFAS. A third reviewer recommended EPA re-examine the part of the statement that says, “but is not sufficient to infer” that PFHxA could cause endocrine effects in humans.

[underlined: EPA Response:] Based on the Tier 1 recommendation from the external peer review committee to reconsider the endocrine effects evidence in light of information on thyroid hormone biology provided by the committee and findings for related PFAS, the overall evidence integration judgement for endocrine effects was changed from evidence suggests but is not sufficient to infer to evidence indicates (likely). The evidence synthesis and integration text in Section 3.2.5 has also been updated to reflect newly identified mechanistic evidence. Consistent with the recommendations from the external peer review committee, decreased serum total T4 from the 28-day rat study by NTP (2018) was advanced for dose response analysis.

[underlined: Comment:] One reviewer recommended EPA delete or provide better justification for the statement, “some of these inconsistencies could be explained by differences in the test article (i.e., PFHxA vs. PFHxA salts)” since both the acids and salts will dissociate at biologically relevant pH to form the identical anion.

[underlined: EPA Response:] This statement was deleted from the text.

#### Tier 2 Suggestions

Reviewers had no Tier 2 suggestions.

### E.2.8 Public Comments on Endocrine Effects

[underlined: Comment:] One commenter disagreed with the conclusion on Endocrine effects, suggesting that the integration judgement should be changed to evidence is inadequate, citing a weak evidence base (i.e., inadequate human evidence and slight animal evidence).

[underlined: EPA Response:] For the reasons described in the EPA response to the tier 1 recommendation from external peer reviewers above, EPA strengthened the overall evidence integration judgment from evidence suggests to evidence indicates based on concluding that the animal evidence is moderate rather than slight.

### E.2.9 External Peer Review Comments on All Other Potential Health Effects

All seven reviewers agreed with the conclusions of the draft Toxicological review for all other potential health effects in the assessment. One reviewer stated they “agreed that the data has been “clearly and appropriately synthesized in order to describe the strengths and limitations of the data” and would in general agree with the comment that these endpoints did not have adequate data to determine impact or not.” Another reviewer commented that, “The Agency clearly characterized both strength and weaknesses of these studies and the conclusion that there is inadequate information to assess whether PFHxA affects these physiological domains is scientifically justified.” Their Tier 1 Recommendations and Tier 2 Suggestions are provided below.

#### Tier 1 Recommendations

[underlined: Comment:] EPA should improve transparency by including observations across other PFAS compounds for the broad list of potential endpoints in this section, either by each endpoint listed in charge question 3(e) or by providing an overall summary table of input from evaluation of other PFOS compounds for these endpoints.

[underlined: EPA Response:] Table 4-1 has been added to the assessment (see Section 4.1) to facilitate comparisons of toxicity hazard conclusions across EPA PFAS assessments.

[underlined: Comment:] For renal effects, EPA should note reverse causality as a concern in the Seo et al. (2018) study and provide a clearer justification for considering Zhang et al. (2019)as “uninformative.”

[underlined: EPA Response:] The evidence synthesis text was edited in Section 3.2.3 to clarify the rationale underlying the study evaluation judgments for these studies. The potential for reverse causality was added as a factor that decreases certainty to the evidence integration table.

#### Tier 2 Suggestions

[underlined: Comment:] EPA should consider re-examining the respiratory effects observed in the 28-day NTP (2018) study and the 90-day Loveless et al. (2009) study for potential incorporation in the Toxicological Review.

[underlined: EPA Response:] The nasal lesions described in the 28-day NTP (2018) study and the 90-day Loveless et al. (2009) study were presumed to be driven by irritation stemming from inadvertent aspiration of the gavage dose. On this basis, the results were considered by EPA to have unclear toxicological relevance and not prioritized for synthesis and integration, however the results are summarized in the animal literature (https://public.tableau.com/profile/literature.inventory#!/vizhome/PerfluorohexanoicAcidPFHxAEvidenceMapVisualization/AnimalStudies) [underlined: inventory]. This rationale is described and a link to the animal literature inventory is provided in Section 3.2 of the Toxicological Review.

[underlined: Comment:] For renal effects, EPA should consider several revisions to Table 3-19: 1) Consider noting the potential for reverse causality as a factor that decreases certainty for the association of PFHxA with decrease in estimated eGFR; 2) consider adding “weak, no, or inconsistent dose-response” as a factor that decreases certainty for organ weight; 3) as a factor that decreases certainty, consider adding that “blood biomarkers of renal function were inconsistent”; and 4) as another factor that decreases certainty, consider adding difficulty in interpreting the observed effects as adverse or non-adverse.

[underlined: EPA Response:] Edits were made to Table 3-19 (Renal profile table for PFHxA) to reflect these suggestions.

[underlined: Comment:] For immune effects, EPA could improve clarity by moving asthma to its own Pulmonary Effects section, since the one human asthma study examined was mostly of non-immune mediated outcomes.

[underlined: EPA Response:] Asthma can be driven by both immune and respiratory effects. Since there is no respiratory effects section in the PFHxA Toxicological Review and the study included evaluation of immune related markers of asthma, the data from this study are retained in the immune effects section.

[underlined: Comment:] In Table 3-37 in the nervous system effects section, EPA should indicate the “preferred metric” for brain weight is absolute brain weight to be consistent with Table 3-31.

[underlined: EPA Response:] This text has been added to Table 3-37 in the nervous system effects section.

[underlined: Comment:] For nervous system effects, zebrafish studies are common for PFAS and should be considered as useful supplemental data to inform evaluations. The reviewer also commented that this section could benefit from discussion of known impacts of other PFAS that might inform design of future studies

[underlined: EPA Response:] Mechanistic information from newly identified studies, including two early life stage zebrafish studies, have been added to the nervous system effects synthesis and integration in section 3.2.9. While these data did not change the conclusions of the assessment, they were included on the basis that they help to inform critical data gaps for nervous system effects.

### E.2.10 Public Comments on All Other Potential Health Effects

[underlined: Comment:] One commenter disagreed with the conclusion that the evidence is inadequate for renal effects. They suggested that histopathological changes observed in the kidney (i.e., papillary necrosis and tubular degeneration) in the chronic rat study by Klaunig (2015) are adverse and should be used as the basis for derivation of the RfD. One commenter agreed with the conclusions for immune and nervous system effects.

[underlined: EPA Response:] The conclusions in the draft Toxicological Review regarding other effects were supported by the external peer review committee. The EPR also supported the conclusions in the draft regarding the renal effects, although there were Tier 1 and 2 comments that were addressed above. The EPA is aware of the report prepared by Luz et al. (2019), and the author conclusion for an RfD based on papillary necrosis in female rats exposed to 200 mg/kg-d PFHxA from the chronic study (Klaunig, 2015, 2850075). While the histopathological renal effects observed by Klaunig et al. (2015) in females were the most significant effect, there were inconsistencies across studies at similar observations times and doses and lack of coherence with other renal findings. Therefore, the judgment of slight animal evidence was retained in the revised assessment. The decision in the draft assessment that overall the renal evidence is inadequate is similarly retained and renal endpoints were not advanced for RfD derivation.

## E.3 CHARGE QUESTIONS 4 AND 5: NONCANCER TOXICITY VALUES DATA SELECTION

4) For PFHxA, no RfC was derived. The study chosen for use in deriving the RfD is the Loveless et al. (2009) one-generation reproductive toxicity study based on decreased offspring body weight in rats exposed continuously throughout gestation and lactation to PFHxA sodium salt via the dam. Is the selection of this study and these effects for use in deriving the RfD for PFHxA scientifically justified and clearly described?
  a. If yes, please provide an explanation.
  b. If no, please provide an alternative study(ies) or effect(s) that should be used to support the derivation of the RfD and detail the rationale for use of such an alternative.
  c. As part of the responses in “a” or “b” above, please comment on whether the effects selected are appropriate for use in deriving the RfD, including considerations regarding adversity (or appropriateness in representing an adverse change) and the scientific support for their selection.
  d. Given the lack of studies on inhalation exposure to PFHxA, no reference concentration (RfC) is derived. Please comment on this decision.
5) In addition, for PFHxA, an RfD for less-than-lifetime (“subchronic”) exposures is derived. No “subchronic” RfC was derived. The same study and outcome were chosen for use in deriving the RfD. Is the selection of this study and these effects for the derivation of the subchronic RfD for PFHxA scientifically justified and clearly described?
  a. If yes, please provide an explanation.
  b. If no, please provide an alternative study(ies) and/or effect(s) that should be used to support the derivation of the subchronic RfD and detail the rationale for use of such an alternative.
  c. As part of the responses in “a” or “b” above, please comment on whether the effects selected are appropriate for use in deriving the RfD, including considerations regarding adversity (or appropriateness in representing an adverse change) and the scientific support for their selection.
  d. Given the lack of studies on inhalation exposure to PFHxA, no “subchronic” RfC is derived. Please comment on this decision.

### E.3.1 External Peer Review Comments on Noncancer Toxicity Values Data Selection

For charge question 4, three reviewers concurred with the selection of the Loveless et al. (2009) study and the effect of decreased offspring body weight as scientifically justified for derivation of an RfD for PFHxA. Two reviewers recommended the NTP (2018) study with serum T4 as an endpoint be used as an alternative.” These comments are described below. Two reviewers noted that the topic is “outside of their expertise” with one stating that “the reasoning presented for RfD derivation appeared sound” while the other declined to comment. “All reviewers who provided comments agreed with the decision to not derive a reference concentration.”

For charge question 5, “reviewers’ comments on the charge questions related to the derivation of the subchronic RfD were similar to those made for the chronic RfD.” Four reviewers “concurred with the selection of the Loveless et al. (2009) study and the selected effect as scientifically justified for derivation of the subchronic RfD for PFHxA. As with the chronic RfD, one reviewer “suggested using the NTP (2018) study with the endpoint of T4 suppression, although they did not include this comment as a tiered recommendation.” Two reviewers noted that the topic is “outside of their expertise” with one stating that “the reasoning presented for RfD derivation appeared sound” while the other declined to comment. “All reviewers who provided comments agreed with the decision to not derive a subchronic reference concentration.”

#### Tier 1 Recommendations

[underlined: Comment:] Two reviewers commented that the EPA should calculate an osRfD using the T4 endpoint from the NTP (2018). Of these, one reviewer recommended EPA “…also calculate this value using the T4 endpoint from the NTP, 2018 study and to determine if this has significant impact on the calculation of the RfD.” This reviewer recommended that, if it does “have a significant impact, then EPA should prioritize the use of the T4 endpoint” for the RfD. The second reviewer recommended EPA use serum T4 as an endpoint should be used as an alternative to support the derivation of an RfD.

[underlined: EPA Response:] Decreases in free and total T4 observed in male rats in the 28 day study by NTP (2018). Total T4 was advanced for derivation of a POD for endocrine effects over free T4 because of concerns about the measurement method variability of the assay used to measure free T4 (see Section 5.2.1). The POD for total T4 was higher than that selected for the developmental osRfD (see Table 5-5). This endpoint was not considered for derivation of a lifetime toxicity value due to the high level of uncertainty associated with use of a short-term study to protect against the effects of a chronic, lifetime exposure. Therefore, total T4 was prioritized for subchronic candidate value derivation.

Calculation of a candidate subchronic toxicity value for total T4 did not affect the overall subchronic RfD selection for the Toxicological Review. As described in Section 5.2.1 (Selection of Subchronic RfD and Confidence Statement), “a subchronic RfD of 5 × 10−4 mg/kg-day based on decreased postnatal body weight is selected for less-than-lifetime exposure. The confidence in the selected subchronic RfD is equivalent to that of the hepatic subchronic RfDs but lower than the hematopoietic subchronic RfD. The developmental subchronic RfD is expected to be protective of all life stages. The UF_C_ (see Table 5-13) is lower than or equivalent to the other subchronic osRfDs and the endpoint has the lowest POD_HED_ (0.048 mg/kg-day, see Table 5-11). The decision to select the developmental subchronic RfD was based on all of the available subchronic osRfDs in addition to overall confidence and composite uncertainty for those subchronic osRfDs.”

#### Tier 2 Suggestions

[underlined: Comment:] EPA should consider adding text to the organ-specific narrative for hepatic effects and for developmental impacts, regarding adversity versus adaptation that may be relevant for the study selection justification and health impacts to the human population. The reviewer noted that these studies were either medium or high confidence studies with good annotation and discussion of observations, and the quantitative estimates resulting from these calculations indicate that these are sensitive hence protective endpoints for use in the RfD development. The reviewer also noted that these endpoint choices for the RfD are highly relevant for human populations.

[underlined: EPA Response:] Additional text was added to Sections 3.2.1, 3.2.2, 4.1 and 5.2.1 to clarify how the observations for hepatic and developmental effects are expected to be adverse, potentially relevant to humans, and coherent across different layers of biology (i.e., from chemical -molecular interaction) to organ level effects (e.g., increased liver weight and necrosis for hepatic effects).

### E.3.2 Public Comments on Noncancer Toxicity Values Data Selection

[underlined: Comment:] One commenter agreed with the endpoints selected for POD derivation and a second agreed with the decision to use high confidence animal studies.

[underlined: EPA Response:] The external peer review panel supported the selection of the endpoints for POD derivation in the draft, although a tier 1 recommendation was made to add decreased T4 for endocrine effects. The assessment has been updated to reflect the panel recommendations.

[underlined: Comment:] Two commenters disagreed with the selection of decreased postnatal body weight for the RfD on the basis that these effects could be driven by maternal toxicity rather than a direct developmental effect and the outcome is non-specific. One also suggested that the RfD should be based on renal effects (papillary necrosis and tubular degradation) from the Klaunig (2015) study.

[underlined: EPA Response:] EPA considered the available evidence base, key science questions, and extensive peer review to develop and justify conclusions that are based on the PFAS protocol and the IRIS Handbook that was favorably reviewed by the National Science Academy. Additional justification and documentation for the rationale underlying this decision is provided in Section 5.

## E.4 CHARGE QUESTIONS 6, 7, AND 8: NONCANCER TOXICITY VALUE DERIVATION

6) EPA used benchmark dose modeling (U.S. EPA, 2012, 1239433) to identify points-of-departure (PODs) for oral exposure to PFHxA. Are the modeling approaches used, selection and justification of benchmark response levels, and the selected models used to identify each POD for toxicity value derivation scientifically justified and clearly described?
7) Appendix A identifies the potential for pharmacokinetic differences across species and sexes as a key science issue and lays out a hierarchy for using relevant pharmacokinetic data in extrapolating oral doses between laboratory animals and humans. Section 5.2.1 describes the various approaches considered and the rationale for the selected approach. Given what is known and not known about the potential interspecies differences in PFHxA pharmacokinetics, EPA used the ratio of human-to-animal serum clearance values assuming the volume of distribution (V_d_) in humans is equivalent to that in monkeys to adjust the POD to estimate a human equivalent dose (HED) in the derivation of the respective RfDs.
  a. Is applying the ratio of human-to-animal serum clearance values for PFHxA scientifically justified and clearly described? If not, please provide an explanation and detail the preferred alternative approach.
  b. Does the Toxicological Review clearly describe the uncertainties in evaluating the pharmacokinetic differences between the experimental animal data and humans?
8) EPA has evaluated and applied uncertainty factors to account for intraspecies variability (UF_H_), interspecies differences (UF_A_), database limitations (UF_D_), exposure duration (UF_S_), and LOAEL-to-NOAEL extrapolation (UF_L_) for PFHxA.
  a. Is uncertainty in the derivation of the toxicity values scientifically justified and clearly described? Please describe and provide comments, if needed.
  b. For uncertainty in interspecies differences (UF_A_), a value of 3 is applied to account for remaining uncertainty in characterizing the pharmacokinetic and pharmacodynamic differences between laboratory animals and humans after calculation of the HED. For developmental and hematopoietic outcomes, the evidence base lacked chemical-and species-specific information that would have been useful for informing the UFA; for hepatic outcomes, however, available mechanistic and supplemental information was useful for further evaluating the interspecies uncertainty factor. Some data indicate a PPARα-dependent pathway that might support a UF_A_ of 1. Evidence for non-PPARα modes of action, however, is available in the PFHxA (and larger PFAS) database. Thus, uncertainty remains regarding the potential differences in sensitivity across species due to the involvement of both PPARα-dependent and-independent pathways. Further, data are lacking to determine with confidence the relative contribution of each of these pathways. As such, the Toxicological Review concludes the available data are not adequate to determine if humans are likely to be equally or less sensitive than laboratory animals with respect to the observed hepatic effects and that a value of UF_A_ = 3 is warranted to account for the residual uncertainty in pharmacodynamic differences across species. Please comment on whether the available animal and mechanistic studies support this conclusion and whether the analysis presented in the Toxicological Review is scientifically justified and clearly described.
  c. To inform uncertainty in intraspecies variability (UF_H_), the assessment evaluates and considers the available evidence on potential susceptibility to PFHxA within different populations or lifestages, including any potential human health impacts from early life exposure. Are the available information and data appropriately considered and the resultant UF_H_ values scientifically justified and clearly described?
  d. Are the provided rationales for the remaining uncertainty factors (UF_L_, UF_D_, UF_S_) scientifically justified and clearly described? If not, please explain.

### E.4.1 External Peer Review Comments on Noncancer Toxicity Value Derivation

For charge question 6, as summarized in the contractor report, “all reviewers who provided responses to this charge question concurred that the approaches used, and the identification of PODs were scientifically justified and clearly described. Faustman was impressed with the details provided to identify the PODs for exposure to PFHxA and found the tables very easy to use.” Two reviewers “declined to comment, stating that this topic was outside of their area of expertise.”

For charge question 7, “reviewers who provided responses to this charge question generally concurred that the approach used for potential interspecies differences in PFHxA pharmacokinetics was scientifically justified and clearly described. The same reviewers stated that the Toxicological Review clearly described the uncertainties. Several reviewers provided recommendations for improving the clarity.” These are described below. Two reviewers “declined to comment, stating that this topic was outside of their area of expertise.”

For charge question 8, “reviewers had mixed responses when commenting on the UF_A_ of 3. All reviewers who responded to Charge Question 8c concurred with a UF_H_ of 10.” Two reviewers “declined to comment, stating that this topic was outside of their area of expertise.” Four reviewers “provided several comments related to the remaining uncertainty factors.” These comments are described below.

#### Tier 1 Recommendations

[underlined: Comment:] If models that do not provide adequate fit are included in the tables summarizing benchmark dose modeling results for different endpoints (in Appendix B), they should be marked/identified as such in these tables (e.g., by placing the model names and associated estimates in parentheses)

[underlined: EPA Response:] Appendix B has been edited to provide additional clarity and transparency on the modeling results and decisions. All model results are provided in the summary tables and footnotes indicate whether data sets were determined to be inappropriate for modeling or when there was inadequate fit for all models. In instances where there was adequate fit for one or more models, bolded text indicates the selected model and associated values (explained in footnote).

[underlined: Comment:] In Table B-25, the selected model (indicated by bold type in the table and shown in the proceeding figure) has neither the lowest AIC nor lowest BMDL. While an explanation of this was provided by EPA during the peer review meeting, EPA should provide an explanation in the modeling appendix.

[underlined: EPA Response:] After additional review and discussion with BMD modelers, it was determined that this data set is not appropriate for BMD modeling because there is a single dose group showing a high incidence response (50%) in contrast to no response in all other groups. On this basis, a NOAEL approach was used for POD derivation for this endpoint. Tables 5-5 and 5-10 which show the PODs considered for derivation of the RfD and subchronic have been updated to reflect this change in the toxicity value derivation approach. Because this endpoint was not prioritized for derivation of the hepatic chronic or subchronic osRfD selections or the overall RfD or subchronic RfD there was no effect on the derived toxicity values for the Toxicological Review.

[underlined: Comment:] The pharmacokinetic assumptions and parameterizations used by EPA in the httk: High-Throughput Toxicokinetics package should be briefly mentioned/discussed in the Toxicological Review (since httk is a publicly available EPA “product”) and the context for making comparisons with the assumptions and parameterizations of the pharmacokinetic modeling performed for this Review should be clarified.

[underlined: EPA Response:] httk is a tool for rapid risk ranking to identify chemicals for which more in-depth, chemical-specific analyses should be conducted. The httk project at EPA advises against using this approach for this IRIS assessment, noting that the in vitro data used as inputs do not capture the large sex differences seen for many PFAS. On this basis, EPA determined that such an evaluation of httk would not be an appropriate addition to this assessment.

[underlined: Comment:] The reasoning behind using CL as opposed to t1/2 uses two conflicting lines of reasoning and clarification is needed.

[underlined: EPA Response:] Clarifying text was added to Section 5.2.1 (Approach for Animal-Human Extrapolation of PFHxA Dosimetry) that included explanation of EPA’s guidelines on using allometric scaling for deriving oral reference doses and that while there was not PBPK data available for PFHxA, there was TK data.

#### Tier 2 Suggestions

[underlined: Comment:] Given the lack of sex differences observed in human studies, EPA should consider clarifying the text implying that female human and male human equivalent doses will be calculated on the basis of sex-specific PODs in animals.

[underlined: EPA Response:] Clarifying text was added to Section 5.2.1 (Approach for Animal-Human Extrapolation of PFHxA Dosimetry).

[underlined: Comment:] Discussion of the Pérez et al. study should note that some of the results were called into question for PBFA and some of these issues could also apply to PFHxA. EPA should also consider avoiding use of the Pérez study as supplemental information, or if used, to include a caveat per the additional studies referenced by the reviewer.

[underlined: EPA Response:] Clarifying text was added to Section 3.1.2 (Distribution in Humans).

[underlined: Comment:] The reference to slower elimination at higher concentrations (Dzierlenga et al.) was noted as opposite the expectation of saturable renal absorption (mediated by Oatp1a1). The reviewer noted that Han et al. mentions other transporters that have been tested for activity with PFAS and suggested EPA consider adding a clarification such as: “While saturation of reabsorption transporters would lead to decreased half-life, there are also transporters responsible for elimination of PFAS to urine, and saturation of these transporters, such as Oat 1 and Oat3, could lead to an increase in observed half-life and could thereby help explain the observations of Dzierlenga et al.”

[underlined: EPA Response:] Clarifying text was added to Section 5.2.1 (Approach for Animal-Human Extrapolation of PFHxA Dosimetry).

[underlined: Comment:] If EPA decides to maintain a value of 3 for UF_A_, then a value of 10 should be adopted for UF_D_.

[underlined: EPA Response:] As described in EPA’s A Review of the Reference Dose and Reference Concentration Processes (U.S. EPA, 2002), the interspecies uncertainty factor (UF_A_) is applied to account for extrapolation of animal data to humans; it accounts for uncertainty regarding the pharmacokinetic and pharmacodynamic differences across species. Although the pharmacokinetic uncertainty is mostly addressed through the application of dosimetric approaches for estimating human equivalent doses, there is residual uncertainty around the pharmacokinetics and the uncertainty surrounding pharmacodynamics. Typically, a threefold UF is applied for this uncertainty in the absence of chemical-specific information. This is the case for the hematopoietic and developmental endpoints. For the hepatic endpoints, known species differences exist between rodent and human hepatic response to hepatotoxicant, particularly for effects mediated by PPARα (Hall et al., 2012). Although the available evidence from PFAS structurally similar PFHxA were available, experiments specifically challenging the role of PPARα in PFHxA mediated hepatotoxicity were not available. Thus, based on the residual uncertainty surrounding the interspecies differences in pharmacodynamics described above, a factor of 3 is applied to account for the pharmacodynamic uncertainty of the UFA for all potential health effect consequences of PFHxA exposure.

A UF_D_ of 3 is applied because the evidence base for hepatic, hematopoietic, and developmental endpoints included two subchronic studies and one chronic study in Sprague Dawley rats and developmental/reproductive studies in Sprague Dawley rats and Crl:CD1 mice. Limitations, as described in U.S. EPA (2002) were used as the basis for a UF_D_ = 3. These limitations included a lack of informative human studies for most outcomes, subchronic or chronic toxicity studies in more than one species, multigenerational study, a developmental neurotoxicity study. Additionally, the data to inform effects on thyroid hormones is limited to a single short term study.

Additional justification has been provided in the draft in Section 5 to clearly document the rationale for UF selection.

[underlined: Comment:] For the UF_S_ for hepatocellular hypertrophy, EPA should consider including a discussion of the specific study results justifying the specific UF_S_ value proposed (i.e., 3 instead of 10).

[underlined: EPA Response:] Additional text was added to Table 5-6 to clarify EPA’s rationale for selection of a UF_S_ = 3 for hepatic effects. Briefly, hepatocellular hypertrophy observed in the subchronic study is expected to represent a less severe adverse hepatic response than would be expected to occur with chronic exposure. This is expected to reduce the uncertainty with use of a subchronic study.

[underlined: Comment:] For the UF_D_, EPA should consider modifying Table 5-6 to delete “the dose received by the pups is unclear and might be significantly less than that administered to the dams” as a cited factor that in a meaningful way diminishes confidence in the database relevant to deriving the RfD. Otherwise, since developing organism (e.g., pup) doses are commonly unknown, by EPA’s reasoning a UF_D_ of 3 might automatically be applied any time the basis for an RfD or candidate RfD is developmental effects. Moreover, it is not needed as the EPA cites other considerations that are sufficient to support a UF_D_ of 3.

[underlined: EPA Response:] This text was removed.

[underlined: Comment:] EPA should consider adding a more explicit description of the reasoning for choosing a UF_A_ of 3 instead of 1 or 10.

[underlined: EPA Response:] Clarifying text was added to Section 5.2.1 (Derivation of Candidate Toxicity Values for the RfD) to support the rationale for the UF_A_ = 3.

[underlined: Comment:] EPA should consider revising the UF_S_ of 1 to 10. The reviewer stated that the UF_S_ of 1 does not seem to consider the data showing that PFHxA exposure causes a reduction in serum thyroid hormone, but there is little information beyond that. Moreover, there is data suggesting that eye-opening is delayed by PFHxA exposure, which is a potential thyroid endpoint, but this relationship is not evaluated empirically. Considering this, the UF_S_ of 1 does not appear to cover this level of uncertainty for development.

[underlined: EPA Response:] The reviewers concerns seem to be more directly related to lack of additional data to inform the endocrine effects of PFHxA exposure. Limitations of the evidence base are accounted for with the database uncertainty factor (UF_D_). Additional text was added to the UF_D_ justification in Table 5-6 to address the data gap described by the reviewer. Additionally, in the current version of the draft, decreased serum free T4 was brought forward for dose response analysis in support of the subchronic reference dose (RfD) and a UF_S_ = 10 was applied to this endpoint.

### E.4.2 Public Comments on Noncancer Toxicity Value Derivation

[underlined: Comment:] Two commenters agreed with the data-driven HED approach used in the toxicological review. One commenter disagreed with the selected approach on the basis that there is insufficient evidence to support the data driven approach used in the assessment and suggest that the BW3/4 approach should be used for calculation of the POD_HED_.

[underlined: EPA Response:] The HED approach in the draft Toxicological Review was supported by the external peer review committee. Some clarifying text was added to the draft in response to some tier 1 and tier 2 recommendations from the panel.

[underlined: Comment:] One commenter indicated that they supported selection of a UF_S_ = 1 for hematopoietic effects but suggested EPA reconsider a UF_S_ = 3 for hepatic effects. Specifically, they state that “the rationale for application of a UF_S_ should consider whether adverse effects occur at a lower dose with longer exposure, not only that adverse effects at a certain dose become more severe with longer exposure” They suggest that a UF_S_ = 1 may be appropriate for hepatic effects similar to that used by DWQI (2017) for PFOA. Another commenter suggested that it was inappropriate to EPA should not use a subchronic study and an uncertainty factor for derivation of a lifetime toxicity value when data are available from a chronic study.

[underlined: EPA Response:] As explained in the assessment, a UF_S_ of 3 is applied to hepatocellular hypertrophy for the purpose of deriving a lifetime RfD. Although the endpoint was derived from a 90-day subchronic study (Loveless et al., 2009), which would typically warrant application of a UF_S_ = 10, there are some other sparse data that mitigate this uncertainty, to an extent. Specifically, significant hepatocellular hypertrophy was not observed in the chronic study in male or female rats (Klaunig et al., 2015). However, a UF_S_ = 1 was not applied as the evidence supports a pathway where hepatocellular hypertrophy is an adverse event leading to more severe outcomes with longer exposure durations, such as the necrosis that was observed in female rats in the chronic study. Additionally, the highest dose levels used in the chronic study were at or below the LOAEL for this effect in the available subchronic studies (see Section 3.2.1). Thus, some uncertainty remains and a UF_S_ of 3 is applied.

A UF_S_ of 3 is also applied to the hematopoietic endpoint (i.e., decreased RBCs) from the 90-day subchronic study (Chengelis et al., 2009b). Specifically, a UF_S_ lower than 10 was warranted as more significant effects on RBCs were not observed after chronic exposure at the same PFHxA doses (RBCs decreases of the same magnitude were observed at matched doses and sexes across exposure durations see Section 3.2.4); however, uncertainty remains when considering the doses tested in the chronic as compared to the subchronic study. Further, the subchronic study may poorly predict a chronic exposure setting across multiple RBC life cycles (one cycle is ~60 days), which could reflect cumulative effects as greater proportions of RBCs across stages are affected, or possibly even reduced effects (compensatory responses) warranting a UF_S_ higher than 1. Thus, a UF_S_ of 3 was applied.

[underlined: Comment:] One commenter suggested that the lack of informative human data should not be accounted for in the UF_D_ = 3 and indicates questionable human relevance of the animal findings.

[underlined: EPA Response:] EPA’s A Review of the Reference Dose and Reference Concentration Processes (U.S. EPA, 2002) states that the “database UF is intended to account for the potential for deriving an underprotective RfD/RfC as a result of an incomplete characterization of the chemical’s toxicity.” The document recommends “…the assessor should consider both the data lacking and the data available for particular organ systems as well as life stages” when determining the value of the UF_D_. Because reliable human data is the most relevant for assessing risk of an exposure to humans, the lack of informative human studies presents an important gap in the evidence base.

[underlined: Comment:] One commenter agreed with the BMR selections. Another suggested that additional support including references are needed to support the BMR justifications.

[underlined: EPA Response:] The modeling approach in the draft Toxicological Review was supported by the external peer review committee. In addition, the assessment cites and follows EPA guidance on BMR selection, which includes additional references and information.

[underlined: Comment:] One commenter disagrees with the decision to use a BMD approach for datasets where there is a response only at one dose (e.g., the highest dose group) regardless of whether the software states that models are viable suggesting that a NOAEL/LOAEL approach be used in these instances. They specifically cite the following endpoints but indicate this list may not be exhaustive: decreased RBC in female rats (Klaunig 2015); decreased hemoglobin in female rats (Klaunig 2015; Loveless 2009); and increased hepatocellular hypertrophy in female rats (Loveless 2009)

[underlined: EPA Response:] All datasets were reviewed for the appropriateness of a BMD approach for POD derivation. For decreased hemoglobin in male rats from Chengelis et al. (2009b) it was determined that the data set was not appropriate for BMD modeling on the basis that the response in the high dose group was much larger than the BMR and there was no response in all other dose groups thus the NOAEL/LOAEL approach was applied to this endpoint (Appendix B, Section B.5). For increased hepatocellular hypertrophy in female rats from Loveless et al. (2009) the dataset was not appropriate for BMD modeling on the basis that the response in the high dose group (50%) is much larger than the BMR and there was no response in all other dose groups (Appendix B, Section B.16). Additional text has been added to modeling appendix has been updated to provide clarify situations in which a NOAEL/LOAEL approach would be preferred over a BMD approach (Appendix B, Section B.3).

[underlined: Comment:] One commenter expressed concern that the osRfD for hematopoietic effects is higher than the subchronic osRfD on the basis that, “It is not logical or supportable to conclude that a specific toxicological effect will occur at a much lower dose from subchronic exposure than from chronic exposure.”

[underlined: EPA Response:] The EPA carefully evaluated the hematopoietic endpoints for toxicity value derivation considering several factors that formed the basis for the overall osRfD and subchronic osRfD. The specific toxicological endpoint, decreased red blood cells, was available from both the chronic and subchronic studies, however it was noted that while the subchronic osRfD is lower (~7-fold) than the chronic osRfD and both subchronic and chronic exposure designs and study durations include the life cycle of a red blood cell (~60 days in rats), the subchronic study duration may miss longer term (or even compensatory) effects on RBCs (i.e., regeneration) that would be observable in a chronic study. Further, confidence in the quantification of the POD for the subchronic osRfD is low given the POD was far below the NOAEL (50 mg/kg-d) and the osRfD is far below toxicity values derived for the same finding from other subchronic studies suggesting some underlying variability is driving the POD lower. These weaknesses and uncertainties in the ability to reliably estimate toxicity values for the hematopoietic effects observed in the 90-day study by (Chengelis et al., 2009b) reduce the confidence in those estimates, which is reflected in two ways. First, there is less confidence in the (Chengelis et al., 2009b) candidate value for lifetime exposure, as compared to the value based on the chronic study, and, although the candidate value from the subchronic study is lower, the higher confidence data from the longer-term study is selected for the lifetime osRfD. Second, for the subchronic osRfD, although data from the (Chengelis et al., 2009b) is ultimately selected because the chronic study is not applicable and the POD from (Chengelis et al., 2009b) was much lower and more protective than PODs from the other subchronic studies, this value was interpreted as medium-low confidence overall given the aforementioned uncertainties. Based on this lower confidence determination, this subchronic osRfD is not used to support the overall subchronic RfD. The EPA added this additional clarification to Section 3.2.1, and Section 5.2.1.

## E.5 CHARGE QUESTION 9 AND 10: CARCINOGENICITY HAZARD IDENTIFICATION AND TOXICITY VALUE DERIVATION

9) The Toxicological Review concludes that there is inadequate information to assess carcinogenic potential for PFHxA and that this descriptor applies to oral and inhalation routes of human exposure. Please comment on whether the available animal and mechanistic studies and the analysis presented in the Toxicological Review are scientifically justified and clearly described.
10) Given the conclusion there was inadequate information to assess carcinogenic potential for PFHxA (Charge Question 5), the Toxicological Review does not derive quantitative estimates for cancer effects for either oral or inhalation exposures. Is this decision scientifically justified and clearly described?

### E.5.1 External Peer Review Comments on Carcinogenicity Hazard Identification and Toxicity Value Derivation

“All reviewers concurred that the analysis presented in the Toxicological Review was scientifically justified and clearly described.”

#### Tier 1 Recommendations and Tier 2 Suggestions

Reviewers had no Tier 1 recommendations or Tier 2 suggestions.

### E.5.2 Public Comments on Carcinogenicity Hazard Identification and Toxicity Value Derivation

[underlined: Comment:] One commenter agreed with the conclusion that there is inadequate information to assess carcinogenic potential of PFHxA, noting that carcinogenicity has only been evaluated in a single study of one species (rat).

[underlined: EPA Response:] NA

## E.6 ADDITIONAL COMMENTS

### E.6.1 Additional External Peer Review Comments

Two reviewers “provided additional comments separately from their responses to the charge questions. These included the following tiered comments not already covered in their responses to charge questions.”

#### Tier 1 Recommendations

Reviewers had no Tier 1 recommendations.

#### Tier 2 Suggestions

[underlined: Comment:] EPA should consider how data from other PFAS either support or differ from PFHxA observations and how those could be explained by structure-activity relationships (e.g., chain length vs. half-live observations) as well as how data from other model systems (e.g., zebrafish) could help to fill data gaps.

[underlined: EPA Response:] Additional comparisons from other PFAS were added to the draft toxicological review, specifically drawing from other observations in PFAS. Examples include the discussion in the hepatic effects Section 3.2.1, subsection Considerations Related to Human relevance, and Table 4-1 in Section 4.1. Note that information from the supplemental evidence that was determined to be potentially impactful to assessment conclusions (that may evaluate effects on model systems other than animal and human) were captured and incorporated into the assessment.

[underlined: Comment:] EPA should consider harmonizing the discussion of supporting evidence across the different endpoints considered. For example, if structure-activity relationship information is available for hepatic effects and the document includes text on what should be expected for PFHxA based on observations for other PFAS, then under developmental effects, the document should state whether similar structure-activity relationships could be considered or if such information is not available

[underlined: EPA Response:] Similar to the comment above, the EPA included additional information from other PFAS particularly in Section 4, and summarized in Table 4.1, into the assessment. The evidence from other PFAS in models evaluating effects similar to PFHxA were considered.

[underlined: Comment:] EPA should consider adding context on reliability for the information presented in Table 1-1 on the available physicochemical properties of PFHxA. The reviewer noted, for example, that water solubility of ammonium vs. sodium salts varies five orders of magnitude and stated that “clearly one of these values is wrong as once dissociated these should behave similarly.” Similarly, the reviewer noted that the same is true for the bioconcentration factor.

[underlined: EPA Response:] Text was added to Section 1.1.1 to clarify that the data in the table represent both experimental and predicted values and that the predicted values may be less reliable. Footnotes are used in Table 1-1 to indicate which values are experimental and which are predicted.

[underlined: Comment:] In the pharmacokinetics background (Section 3.1) of the Toxicological Review, EPA should consider clarifying how “substantial binding” to serum proteins is defined (see page 3-5, lines 6-7). The reviewer noted that PFHxA has been shown in in vitro studies to bind less strongly than long-chain PFAS.

[underlined: EPA Response:] The text was edited to indicate the percent binding reported in the study (>99% bound to serum albumin).

### E.6.2 Additional Public Comments

[underlined: Comment:] One commenter suggested that EPA expand the background information section on sources and relative contributions of PFHxA sources to better support the case for human exposures. They also recommend that EPA present exposure information for PFHxA relative to other PFAS compounds.

[underlined: EPA Response:] Comprehensive evaluation of exposure is outside the scope of IRIS assessments. The background information described in Section 1.1 is an overview and is not intended to provide a comprehensive description of the available information on PFHxA and related salts, and information on human exposure is tagged as supplemental information during the screening process.

[underlined: Comment:] One commenter suggested changes to the integration judgement language (i.e., “the available evidence indicates that PFHxA exposure is likely to cause X effects in humans, given relevant exposure circumstances”) on the basis that it implies causation. Alternative language was suggested. Specifically, “the available evidence indicates that PFHxA could potentially result in an increased risk of X in humans if exposure to exceeds XXX on a mg/kg-day basis.”

[underlined: EPA Response:] The integration judgement language in the Toxicological Review is consistent with the peer-reviewed IRIS Handbook.

[underlined: Comment:] One commenter suggested that EPA apply an additional uncertainty factor to account for potential additive effects of exposure to multiple PFAS chemicals.

[underlined: EPA Response:] EPA applied uncertainty factors to account for five possible areas of uncertainty as described in “Derivation of Candidate Values for the RfD,” and in U.S. EPA (2002). This assessment is specific to PFHxA and its related salts and the consideration of a potential additive effect of exposure to multiple PFAS chemicals would not be appropriate for a scientific document developed for one PFAS. The consideration of potential additive effects of exposure to multiple PFAS would be part of the risk assessment and risk management activities such as the application of this assessment (once finalized) along with other relevant assessments by risk managers addressing human exposure to multiple PFAS. Thus, this is outside of the scope of the IRIS Program.

1 Newly identified studies (i.e., studies identified by EPA or the public that meet PECO criteria but were not addressed in the external review draft, for example due to recent publication) will be characterized by EPA and presented to the peer review panel. This characterization will focus on EPA’s judgment of whether the studies would have a material impact on the conclusions (i.e., identified hazards or toxicity values) in the external review draft. The peer review panel is asked to review EPA’s characterization and provide tiered recommendations to EPA regarding which studies, if any, to incorporate into the assessment before finalizing.