# APPENDIX D QUALITY ASSURANCE FOR THE IRIS TOXICOLOGICAL REVIEW OF PFHXA

This assessment is prepared under the auspices of the U.S. Environmental Protection Agency’s (EPA’s) Integrated Risk Information System (IRIS) Program. The IRIS Program is housed within the Office of Research and Development (ORD) in the Center for Public Health and Environmental Assessment (CPHEA). EPA has an agency-wide quality assurance (QA) policy outlined in the EPA Quality Manual for Environmental Programs (see CIO 2105-P-01.1 (https://www.epa.gov/irmpoli8/environmental-information-quality-procedure)) and follows the specifications outlined in EPA Order CIO 2105.1 (https://www.epa.gov/irmpoli8/environmental-information-quality-policy).

As required by CIO 2105.1, ORD maintains a Quality Management Program, which is documented in an internal Quality Management Plan (QMP). The latest version was developed in 2013 using Guidance for Developing Quality Systems for Environmental Programs (QA/G-1) (https://www.epa.gov/quality/guidance-developing-quality-systems-environmental-programs-epa-qag-1). A National Center for Environmental Assessment (NCEA)/CPHEA-specific QMP also was developed in 2013 as an appendix to the ORD QMP. Quality assurance for products developed within CPHEA is managed under the ORD QMP and applicable appendices.

The IRIS Toxicological Review of PFHxA is designated as Influential Scientific Information (ISI) and is classified as QA Category A. Category A designations require reporting of all critical QA activities, including audits. The development of IRIS assessments is done through a seven-step process. Documentation of this process is available on the IRIS website: https://www.epa.gov/iris/basic-information-about-integrated-risk-information-system#process.

Specific management of PFAS assessments is documented in a Programmatic Quality Assurance Project Plan (PQAPP). A PQAPP is developed using the EPA Guidance for Quality Assurance Project Plans (QA/G-5) (https://www.epa.gov/quality/guidance-quality-assurance-project-plans-epa-qag-5), and the latest approved version is dated October 2021. All PFAS assessments follow the PFAS PQAPP, and all assessment leads and team members are required to receive QA training on the PFAS PQAPP. During assessment development, additional QAPPs may be applied for quality assurance management. They include:

Title | Document number | Date
Program Quality Assurance Project Plan (PQAPP) for PFAS Assessments | L-CPAD-0031652-QP-1-5 | February 2023
Program Quality Assurance Project Plan (PQAPP) for the Integrated Risk Information System (IRIS) Program | L-CPAD-0030729-QP-1-5 | June 2022
An Umbrella Quality Assurance Project Plan (QAPP) for Dosimetry and Mechanism-Based Models (PBPK) | L-CPAD-0032188-QP-1-2 | December 2020
Quality Assurance Project Plan (QAPP) for Enhancements to Benchmark Dose Software (BMDS) | L-HEEAD-0032189-QP-1-2 | October 2020
ICF-General Support of CPHEA Human Health Assessment Activities QAPP | L-CPAD-0031961-QP-1-2 | April 2021

During assessment development, this project undergoes quality audits during assessment development including:

Date | Type of audit | Major findings | Actions taken
August 2019 | Technical System Audit | None | None
August 2020 | Technical System Audit | None | None
July 2021 | Technical System Audit | None | None
August 2022 | Technical System Audit | None | None

During Step 3 and Step 6 of the IRIS process, the IRIS toxicological review is subjected to external reviews by other federal agency partners, including the Executive Offices of the White House. Comments during these IRIS process steps are available in the docket EPA-HQ-ORD-2021-0561 on http://www.regulations.gov.

During Step 4 assessment development, the IRIS Toxicological Review of Perfluorohexanoic Acid and Related Salts underwent public comment from February 2, 2022, to April 4, 2022. Following this comment period, the toxicological review underwent external peer review by a contractor-led panel performed by ERG from April 5,2022 to August 25,2022. The peer-review report is available on the peer review website (https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=353986). All public and peer-review comments are available in the docket EPA-HQ-ORD-2021-0561.

Prior to release (Step 7 of the IRIS process), the final toxicological review is submitted to management and QA clearance. During this step the CPHEA QA Director and QA Managers review the project QA documentation and ensure that EPA QA requirements are met.