# APPENDIX C EVALUATION OF PFHXA ELIMINATION

## C.1 EVALUATION OF PFHXA ELIMINATION IN RATS AND MICE

Pharmacokinetic parameters were estimated separately for male and female rats and mice using a hierarchical, Bayesian framework to allow for the partial pooling of time-course concentration data across multiple studies. Data extracted from the studies described above were fit to the following model formulation, which describes the absorption (when necessary), distribution, and elimination phase of PFHxA through a two-compartment pharmacokinetic model:

C_i_ = a b s_f l a g , i_ ( − A_i_ − B_i_ ) e^− k_a b s , i_ t^ + A_i_ e^− α_i_ t^ + B_i_ e^− β_i_ t^ (C-1)

Here, i represents the ith compartment for PFHxA measurement (e.g., plasma, liver, kidney). A_i_ and B_i_ represent the ratio of chemical mass going to each empirical compartment, normalized by the central compartment volume, resulting in units of PFHxA concentration. For PFHxA concentrations measured in the plasma (i.e., central compartment) following intravenous (i.v.) exposure, abs_flag,i_ is set to zero to remove the absorption term.

Conventionally, each compartment with pharmacokinetic data is fit independently to equation C-1 and tissue-specific half-lives for each species and sex are derived from the estimated β, i.e., t_1/2,I_ = ln(2)/β_i_. However, when a compound is in the elimination phase, β should be constant across all tissues. To determine this PFHxA-specific β and use the time-course concentration data from every study across multiple compartments, a partial pooling of data in a hierarchical Bayesian framework assumes that, although β_i_ differs for each tissue, they are all sampled from a common group distribution. Following completion of the Markov-chain Monte Carlo analysis, the top-level posterior distribution of β is used to determine the median PFHxA half-life, with uncertainty, for each species/sex. The remaining study-level coefficients are used to estimate the additional pharmacokinetic values, for example, area under the curve (AUC_inf_), clearance (CL), volume of distribution (V_dβ_).

Along with the half-life analysis, a separate distribution of CL = dose/AUC_inf_ and V_dβ_ = CL/β is generated for each experiment (study/route/dose/sex), where AUC_inf_ is obtained by integrating equation (C-1) from time = 0 to infinity, to yield

A U C_inf , i_ = (A_i_)/(α_i_) + (B_i_)/(β_i_) − (a b s_f l a g , i_ ( A_i_ + B_i_ ))/(k_a b s , i_) (C-2)

Median and 5th and 95th percentiles of the distributions for t_1/2,I_, CL_i_ and V_dβ_ are then pooled across each study/route/dose to calculate the species- and sex-dependent values.

### C.1.1 Mice

Data for male and female mice were obtained from Gannon et al. (2011) who evaluated the pharmacokinetics after single oral doses of 2 and 100 mg/kg. Original data files were provided by e-mail from Shawn Gannon, The Chemours Company, Wilmington, Delaware to Paul Schlosser, U.S. EPA, Durham, North Carolina on January 23, 2020. Although the data for the 2 mg/kg dose appeared appropriately censored below the dose-specific limit of quantification (LOQ), the 100 mg/kg data appeared to reach a plateau just above the corresponding LOQ (~0.25 µg/g plasma), in a concentration range for which clearance after the 2 mg/kg dose was quite rapid. EPA interpreted this result as indicating an interfering background signal. For this reason, only data with measured concentration >0.5 µg/g plasma were used for the 100 mg/kg dose. The resulting statistics for the elimination half-lives (90% confidence interval) are 2.8 hours (1.0−7.0 hours) and 6.7 hours (2.2−16 hours) for females and males, respectively.

Female mouse data were from Daikin Industries (2010), who exposed groups of mice to 35, 175, or 350 mg/kg PFHxA by oral gavage and measured serum concentration at time-points up to 24 hours. Because three separate mice were analyzed at each time point, means and standard deviations were calculated and used for statistical modeling. Data at the first time points with concentrations below the lower limit of quantification (LLOQ) were assigned a value of LLOQ/√2 for the purpose of computing the means. Specifically, for the 24-hour time point, two of three animals in the 175 and 350 mg/kg dose groups had results <LLOQ, so the substitution was made for those animals prior to calculating the time-point mean. In the 35 mg/kg group, one animal had results <LLOQ at 6 hours so the substitution was made prior to calculating the mean. Because all animals in this group were below LLOQ at 8 hours, the value for that time point was treated as equal to LLOQ/√2, and the results for the 24-hour time-point were censored. Finally, in the 175 mg/kg group, 1 animal in the 8-hour group had a reported concentration 15 times higher than the other 2 animals in that group, 80% higher than the average concentration for that dose at 6 hours and higher than any animal in the 350 mg/kg group at the same time point (8 hours). Therefore, this measurement was censored.

Fits of the pharmacokinetic (PK) model curves to the data sets are shown below. Median and 5th, and 95th percentile values for each parameter are provided in Table 5-3 (see Section 5.2.1, Approach for Animal-Human Extrapolation of PFHxA Dosimetry).

Figure C-1 Fits of population pharmacokinetic model to data for male (top row) and female (remaining rows) mice following 2–350 mg/kg oral exposure PFHxA

Figure C-1, a series of pharmacokinetic models displaying study data

Source: Data from Gannon et al. (2011) and Daikin Industries (2010).

### C.1.2 Rats

PFHxA the following PK data for male and female rats were evaluated:

- Chengelis et al. (2009a): male and female Sprague-Dawley rats exposed once by intravenous injection (i.v.; 10 mg/kg) or by single-day or Day 25 of repeated gavage (50, 150, or 300 mg/kg). (i.v. data for males and females and oral data for males are provided in published tables. Oral data for females were obtained by digitizing the plot of single-day exposure data. The 25-day female rat data, however, were not digitized or used because the digitization process has some uncertainty; reported dose-specific half-lives for females were quite similar for the single- and 25-day studies, and results for males were similar with and without the 25-day data.)
- Dzierlenga et al. (2019): male and female Sprague-Dawley rats exposed by i.v. (40 mg/kg) or by gavage (40, 80, or 160 mg/kg; data from National Toxicology Program website).
- Gannon et al. (2011): male and female Sprague-Dawley rats exposed by gavage (2 or 100 mg/kg; data from study authors).
- Iwabuchi et al. (2017): male Wistar rats exposed by gavage (0.1 mg/kg; data from published tables or digitized from figures).

The resulting statistics for the elimination half-lives, clearance values, and volumes of distribution (with 90% confidence intervals) are listed in Table 5-3 (see Section 5.2.1, Approach for Animal-Human Extrapolation of PFHxA Dosimetry).

## C.2 EVALUATION OF PFHXA ELIMINATION IN HUMANS

Data for human PFHxA analysis were extracted from Nilsson et al. (2013) where PFHxA concentrations were measured in the blood of ski wax technicians exposed to PFAS compounds over the course of multiple ski seasons. Because timing of the initial PFHxA exposure and the resulting absorption kinetics are unknown for this population, EPA fit a one-compartment infusion pharmacokinetic model to the reported time-course data:

C_i_ = { (A_i_)/(t_inf , i_ β_i_) ( 1 − e^− β_i_ t_inf , i_^ ) ( 1 − e^− β_i_ ( t − t_inf , i_ )^ ) (A_i_)/(t_inf , i_ β_i_) ( 1 − e^− β_i_ t^ ) i f t ≤ t_inf , i_ i f t > t_inf , i_ (C-3)

Here, i represents the ith ski wax technician and t_inf,i_ represents the time at which exposure to PFHxA ends. All other model parameters are the same as described above for the rat and mouse fits. Briefly, this model assumes a constant exposure to PFHxA throughout the ski season when time is less than t_inf_. Once t_inf_ is reached, PFHxA is eliminated under a first order elimination assumption.

Similar to the methods described for the rat and mouse, β_i_ for each ski wax technician is sampled hierarchically from a population distribution while all other parameters in the model are fit only to the individual technician. Finally, to use limit of detection (LOD) data reported in this study, we implemented a left-censored likelihood function in the Bayesian inference model for samples reported below the LOD (<0.05 ng/mL). This ensured that the likelihood function for these data were sampled only from a probability distribution with an upper bound at the LOD.

Results for each ski wax technician are shown below following sampling of the technician-specific posterior distributions. Technician half-lives (90% credible interval) are presented in the panel for each technician with the population half-life determined to be 11.45 (6.06 – 21.21) days. Technicians 1–8 represent data from the 2007–2008 ski season, when samples were taken late enough in the spring to allow quantification of post-exposure clearance.

Figure C-2 Fits of human PFHxA data from ski-wax technician blood samples

Blue circles represent data above LOD while black triangles are data samples reported at the LOD (<0.05 ng/mL). 90% credible intervals are illustrated with the light blue bands and dashed lines.

Figure C-2, a series of charts displaying human PHFxA data from blood samples