# APPENDIX B BENCHMARK DOSE MODELING RESULTS

As discussed in the body of the report (see Section 5), the endpoints selected for benchmark dose (BMD) modeling were hepatocellular hypertrophy from Chengelis et al. (2009a) and Loveless et al. (2009); hemoglobin and red blood cells from Chengelis et al. (2009a); Loveless et al. (2009), and Klaunig et al. (2015); postnatal body weight decreases from Loveless et al. (2009) and Iwai and Hoberman (2014); and perinatal mortality from Iwai and Hoberman (2014). The animal doses in the studies were used in the BMD modeling and then converted to human equivalent doses (HEDs) using the ratio of animal-to-human serum half-lives.

## B.1 MODELING PROCEDURE FOR CONTINUOUS NONCANCER DATA

BMD modeling of continuous noncancer data was conducted using EPA’s Benchmark Dose Software (BMDS, Version 3.2). For these data, the Exponential, Hill, Polynomial, and Power models available within the software are fit using a benchmark response (BMR) of 1 standard deviation (SD) when no toxicological information was available to determine an adverse level of response. When toxicological information was available, the BMR was based on relative deviation, as outlined in the Benchmark Dose Technical Guidance (U.S. EPA, 2012). An adequate fit is judged on the basis of a χ^2^ goodness-of-fit p-value (p > 0.1), scaled residuals at the data point (except the control) closest to the predefined BMR (absolute value <2.0), and visual inspection of the model fit. In addition to these three criteria for judging adequacy of model fit, a determination is made as to whether the variance across dose groups is homogeneous. If a homogeneous variance model, also referred to as a “constant variance” (CV) model, is deemed appropriate based on the statistical test provided by BMDS (Test 2 for homogeneity of variance), the final BMD results are presented for the CV model. If the Test 2 p-value is significant (p < 0.05), the model is run again while modeling the variance as a power function of the mean to account for this nonhomogeneous variance, also referred to as “non-constant variance” (NCV). If the NCV model provides adequate fit to the variance of the data (i.e., Test 3 p-value > 0.05), the final BMD results are presented for the NCV model. If this nonhomogeneous variance model does not adequately fit the data (i.e., Test 3; p < 0.05), the data set is considered unsuitable for BMD modeling. In some cases, the data may be remodeled after removing one or more of the highest dose groups; if the reduced data can be modeled and results in a better fit in the low-dose region, these results will be presented with information to indicate that one or more dose groups were removed in the results table. In cases where a model with # parameters = # dose groups was fit to the data set and all parameters were estimated and no p-value was calculated that model was not considered for estimation of a point of departure (POD). Among all models providing adequate fit, the benchmark dose lower confidence limit (BMDL) from the model with the lowest Akaike’s information criterion (AIC) was selected as a potential POD when BMDL estimates differed by less than threefold. When BMDL estimates differed by greater than threefold, the model with the lowest BMDL was selected to account for model uncertainty.

For body weight and relative liver weight, a BMR equal to 10% relative deviation (increase or decrease) from the control mean was used based on a biological consideration. For continuous developmental toxicity data, a BMR equal to 0.5 SD was used. The use of 1 SD for the BMR for continuous endpoints is based the observation that shifting the distribution of the control group by 1 SD results in ~10% of animals falling beyond an adversity cutoff defined at the ~1.5 percentile in the control group (Crump, 1995). This roughly approximates the 10% extra risk commonly used as the BMR for dichotomous endpoints. Thus, the use of 0.5 SD for continuous developmental toxicity endpoints roughly approximates the extra risk of 5% commonly used for dichotomous developmental toxicity endpoints; similarly, the BMR for perinatal body weight is half of that for adults (5% vs. 10% relative deviation) based on biological consideration.

## B.2 MODELING PROCEDURE FOR DICHOTOMOUS NONCANCER DATA

BMD modeling of dichotomous noncancer data was conducted using EPA’s Benchmark Dose Software (BMDS, version 3.2). For these data, the Gamma, Logistic, LogLogistic, LogProbit, Multistage, Probit, Weibull, and Dichotomous Hill models available within the software were fit using a benchmark response (BMR) of 10% extra risk (5% extra risk for developmental endpoints and 1% for mortality). The Multistage model is run for all polynomial degrees up to n – 2, where n is the number of dose groups including control. Adequacy of model fit was judged on the basis of χ2 goodness of fit p value (p > 0.1), scaled residuals at the data point (except the control) closest to the predefined benchmark response (absolute value <2.0), and visual inspection of the model fit. Among all models providing adequate fit, the benchmark dose lower confidence limit (BMDL) from the model with the lowest Akaike’s information criterion (AIC) was selected as a potential POD when BMDL values were sufficiently close (within threefold). Otherwise, the lowest BMDL was selected as a potential POD.

## B.3 MODELING PROCEDURE FOR DICHOTOMOUS NONCANCER DEVELOPMENTAL TOXICITY DATA

For dichotomous developmental toxicity data, data for individual animals were requested from the study authors when possible. This allowed the use of the nested logistic model, which statistically accounts for intralitter similarity (the propensity of littermates to respond more like one another than pups from another litter) by estimating intralitter correlation and using litter-specific covariates. Judging model fit for this model is identical to the procedure used for regular dichotomous models. If individual animal data is available, the nested logistic model is used instead of other models; this will be indicated in the results table and individual animal data will not be reported.

For all data types discussed in Sections B.1–B.4, the NOAEL/LOAEL approach may be used in lieu of BMD modeling to derive reference values, for example, when BMD modeling fails. The NOAEL/LOAEL approach may also be taken when a response is only observed in the highest dose group unless the response for that group is sufficiently close to the BMR, in which case BMD modeling results are used to derive values.

## B.4 HEMOGLOBIN—FEMALE RATS (KLAUNIG ET AL., 2015)

Table B-1 Dose response data for hemoglobin in female rats (Klaunig et al., 2015)

Dose (mg/kg-d) | Number of animals | Mean (g/dL) | Standard deviation
0 | 10 | 15.5 | 0.97
5 | 10 | 15.7 | 0.73
30 | 9 | 15.5 | 0.79
200 | 20 | 14.7 | 0.91

Table B-2 Benchmark dose results for hemoglobin in female rats—constant variance, BMR = 1 standard deviation (Klaunig et al., 2015)

Models | Goodness of fit (p-value) | Test 2 (p-value) | AIC | 1 SD | | Scaled residual for dose group near BMD
Models | Goodness of fit (p-value) | Test 2 (p-value) | AIC | BMD | BMDL | Scaled residual for dose group near BMD
Exponential 2 | 0.83237671 | 0.7551 | 127.5023 | 182.1091 | 120.47632 | −0.016328458
Exponential 3 | 0.57454386 | 0.7551 | 129.4505 | 189.9502 | 120.87504 | 0.002065941
Exponential 4 | 0.83237684 | 0.7551 | 127.5023 | 182.0793 | 120.47647 | −0.015845878
Exponential 5 | 0.57331833 | 0.7551 | 129.4525 | 188.501 | 120.85884 | −0.000961421
Hill | NA | 0.7551 | 131.4228 | 42.56095 | 31.718073 | 0.000755846
Polynomial (Poly 3) | 0.56681655 | 0.7551 | 129.4634 | 191.4936 | 123.01116 | 0.00113966
Polynomial (Poly 2) | 0.56681165 | 0.7551 | 129.4634 | 191.4757 | 123.0163 | 0.001201719
Power | 0.57425021 | 0.7551 | 129.451 | 190.1218 | 123.04966 | 0.002120702
Linear | 0.83402366 | 0.7551 | 127.4983 | 182.7286 | 122.7699 | −0.014122961

Bold row indicates the selected model and values.

Figure B-1 Dose response curve for the Linear model fit to hemoglobin in female rats (Klaunig et al., 2015)

X-axis is dose (mg/kg-day), and y-axis is mean level of hemoglobin (g/dL).

Figure B-1 Linear Model

## B.5 HEMOGLOBIN—MALE RATS (CHENGELIS ET AL., 2009B)

Table B-3 Dose response data for hemoglobin in male rats (Chengelis et al., 2009b)

Dose (mg/kg-d) | Number of animals | Mean (g/dL) | Standard deviation
0 | 10 | 15.6 | 0.51
10 | 10 | 15.4 | 0.58
50 | 10 | 15.4 | 0.65
200 | 10 | 14.3 | 1.08

This data set is not considered appropriate for BMD modeling as the response in the high dose group was much larger than the BMR and there was no response in all other dose groups thus the NOAEL/LOAEL approach was applied to this endpoint.

Figure B-2 Dose response data for hemoglobin in male rats (Chengelis et al., 2009b)

X-axis is dose (mg/kg-day), and y-axis is mean level of hemoglobin (g/dL).

Figure B-2, dose response data

## B.6 HEMOGLOBIN—FEMALE RATS (CHENGELIS ET AL., 2009B)

Table B-4 Dose response data for hemoglobin in female rats (Chengelis et al., 2009b)

Dose (mg/kg-d) | Number of animals | Mean (g/dL) | Standard deviation
0 | 10 | 15.6 | 0.46
10 | 10 | 15.8 | 1.4
50 | 10 | 15.2 | 0.85
200 | 10 | 14.6 | 0.83

Table B-5 Benchmark dose results for hemoglobin in female rats—non-constant variance, BMR = 1 standard deviation (Chengelis et al., 2009b)

Models | Goodness of fit (p-value) | Test 3 (p-value) | AIC | 1 SD | | Scaled residual for dose group near BMD
Models | Goodness of fit (p-value) | Test 3 (p-value) | AIC | BMD | BMDL | Scaled residual for dose group near BMD
Exponential 2 | 0.2289302 | 0.0118 | 113.344 | 177.8625 | 106.4881 | 0.107636338
Exponential 3 | 0.2289313 | 0.0118 | 113.344 | 177.8107 | 106.4883 | 0.107765953
Exponential 4 | 0.0996002 | 0.0118 | 115.1073 | 145.8206 | 37.82113 | 0.036336773
Exponential 5 | 0.165197 | 0.0118 | 114.3214 | 53.45159 | 25.38329 | 0.084452285
Hill | NA | 0.0118 | 116.3216 | 68.93813 | 40.08308 | 0.084913389
Polynomial (Poly 3) | 0.2265515 | 0.0118 | 113.3649 | 179.1794 | 109.5823 | 0.105758473
Polynomial (Poly 2) | 0.2265515 | 0.0118 | 113.3649 | 179.1817 | 110.5758 | 0.105711892
Power | 0.2265515 | 0.0118 | 113.3649 | 179.174 | 109.6196 | 0.105830655
Linear | 0.2265515 | 0.0118 | 113.3649 | 179.1809 | 110.1348 | 0.10575497

Both constant and nonconstant variance models failed to model the variance of the data.

Figure B-3 Dose response data for hemoglobin in female rats (Chengelis et al., 2009b)

X-axis is dose (mg/kg-day), and y-axis is mean level of hemoglobin (g/dL).

Figure B-3, dose response data

## B.7 HEMOGLOBIN—MALE RATS (LOVELESS ET AL., 2009)

Table B-6 Dose response data for hemoglobin in male rats (Loveless et al., 2009)

Dose (mg/kg-d) | Number of animals | Mean (g/dL) | Standard deviation
0 | 10 | 15.4 | 0.5
20 | 10 | 15.5 | 0.41
100 | 10 | 4.5 | 0.7
500 | 10 | 9.9 | 2.8

Table B-7 Benchmark dose results for hemoglobin in male rats—non-constant variance, BMR = 1 standard deviation (Loveless et al., 2009)

Model | Goodness of fit (p-value) | Test 3 (p-value) | AIC | 1 SD | | Scaled residual for dose group near BMD
Model | Goodness of fit (p-value) | Test 3 (p-value) | AIC | BMD | BMDL | Scaled residual for dose group near BMD
Exponential 2 | <0.0001 | <0.0001 | 199.3758 | 9.377807 | 7.193218 | −2.377990291
Exponential 3 | <0.0001 | <0.0001 | 239.5418 | 855.7401 | 0 | 0.802984088
Exponential 4 | <0.0001 | <0.0001 | 190.0784 | 6.631732 | 3.474481 | −0.818335738
Exponential 5 | 0.071088 | <0.0001 | 138.3961 | 70.68336 | 21.21839 | −2.570261966
Hill | 0.07109 | <0.0001 | 138.3961 | 38.98926 | 21.0774 | 0.362134233
Polynomial (Poly 3) | <0.0001 | <0.0001 | 239.7107 | 891.7542 | 383.4838 | 0.626839397
Polynomial (Poly 2) | <0.0001 | <0.0001 | 239.7107 | 891.7546 | 383.3929 | 0.626839015
Power | <0.0001 | <0.0001 | 239.7107 | 891.7544 | 383.3928 | 0.626839886

Both constant and nonconstant variance models failed to model the variance of the data.

Figure B-4 Dose response data for hemoglobin in male rats (Loveless et al., 2009)

X-axis is dose (mg/kg-d), and y-axis is mean level of hemoglobin (g/dL).

Figure B-4, dose response data

## B.8 HEMOGLOBIN—FEMALE RATS (LOVELESS ET AL., 2009)

Table B-8 Dose response data for hemoglobin in female rats (Loveless et al., 2009)

Dose (mg/kg-d) | Number of animals | Mean (g/dL) | Standard deviation
0 | 10 | 15.6 | 0.7
20 | 10 | 15.8 | 0.8
100 | 10 | 15.6 | 0.4
500 | 9 | 13.3 | 0.9

Table B-9 Benchmark dose results for hemoglobin in female rats—constant variance, BMR = 1 standard deviation (Loveless et al., 2009)

Model | Goodness of fit (p-value) | Test 2 (p-value) | AIC | 1 SD | | Scaled residual for dose group near BMD
Model | Goodness of fit (p-value) | Test 2 (p-value) | AIC | BMD | BMDL | Scaled residual for dose group near BMD
Exponential 2 | 0.214488 | 0.107799 | 89.79631 | 134.0618 | 104.1801 | 1.219441036
Exponential 3 | 0.50507 | 0.107799 | 89.16158 | 264.9174 | 126.3561 | −0.026708969
Exponential 4 | 0.214489 | 0.107799 | 89.7963 | 134.0137 | 104.1803 | 1.219907658
Exponential 5 | 0.505122 | 0.107799 | 89.16147 | 266.3836 | 126.3586 | −0.034100913
Hill | NA | 0.107799 | 91.14613 | 115.7416 | 102.1374 | −1.06893 × 10^−06^
Polynomial (Poly 3) | 0.800193 | 0.107799 | 87.16312 | 268.4412 | 127.6129 | −0.023130227
Polynomial (Poly 2) | 0.800179 | 0.107799 | 87.16315 | 267.1194 | 127.8182 | −0.018215642
Power | 0.452941 | 0.107799 | 89.2806 | 372.7895 | 126.1226 | 0.000358346
Linear | 0.259194 | 0.107799 | 89.41767 | 141.5272 | 111.6505 | 1.119316772

Bold row indicates the selected model and values.

Figure B-5 Dose response curve for the Polynomial Degree 3 model fit to hemoglobin in female rats (Loveless et al., 2009)

X-axis is dose (mg/kg-d), and y-axis is mean level of hemoglobin (g/dL).

Figure B-5, dose response curve

## B.9 RED BLOOD CELLS—MALE RATS (KLAUNIG ET AL., 2015)

Table B-10 Dose response data for red blood cells in male rats (Klaunig et al., 2015)

Dose (mg/kg-d) | Number of animals | Mean (million/µL) | Standard deviation
0 | 10 | 9.2 | 0.17
2.5 | 10 | 8.8 | 1.52
15 | 9 | 8.66 | 0.92
100 | 19 | 8.8 | 1

Table B-11 Benchmark dose results for red blood cells in male rats—non-constant variance, BMR = 1 standard deviation (Klaunig et al., 2015)

Model | Goodness of fit (p-value) | Test 3 (p-value) | AIC | 1 SD | | Scaled residual for dose group near BMD
Model | Goodness of fit (p-value) | Test 3 (p-value) | AIC | BMD | BMDL | Scaled residual for dose group near BMD
Exponential 2 | <0.0001 | 0.863381 | 143.4547 | 808.9905 | 155.542 | 0.078851
Exponential 3 | <0.0001 | 0.863381 | 143.4551 | 832.8003 | 104.7724 | 0.070665
Exponential 4 | <0.0001 | 0.863381 | 144.0729 | −9999 | 0 | −9999
Exponential 5 | <0.0001 | 0.863381 | 145.454 | 865.033 | 103.3948 | 0.080901
Hill | NA | 0.863381 | 121.2797 | −9999 | 0 | −9999
Polynomial (Poly 3) | <0.0001 | 0.863381 | 143.4552 | 774.4171 | 120.0894 | 0.076434
Polynomial (Poly 2) | <0.0001 | 0.863381 | 143.4552 | 774.9496 | 132.5465 | 0.076318
Power | <0.0001 | 0.863381 | 143.4552 | 775.0219 | 106.6368 | 0.076271
Linear | <0.0001 | 0.863381 | 143.4552 | 775.3403 | 153.4792 | 0.076151

Both constant and nonconstant variance models failed to model the data.

Figure B-6 Dose response data red blood cells in male rats (Klaunig et al., 2015)

X-axis is dose (mg/kg-d), and y-axis is mean level of red blood cells (million/µL).

Figure B-6, dose response data

## B.10 RED BLOOD CELLS—FEMALE RATS (KLAUNIG ET AL., 2015)

Table B-12 Dose response data for red blood cells in female rats (Klaunig et al., 2015)

Dose (mg/kg-d) | Number of animals | Mean (million/µL) | Standard deviation
0 | 10 | 8.14 | 0.52
5 | 10 | 8.23 | 0.58
30 | 9 | 8.12 | 0.37
200 | 20 | 7.48 | 0.68

Table B-13 Benchmark dose results for red blood cells in female rats—constant variance, BMR = 1 standard deviation (Klaunig et al., 2015)

Model | Goodness of fit (p-value) | Test 2 (p-value) | AIC | 1 SD | | Scaled residual for dose group near BMD
Model | Goodness of fit (p-value) | Test 2 (p-value) | AIC | BMD | BMDL | Scaled residual for dose group near BMD
Exponential 2 | 0.896578 | 0.204474 | 88.37423 | 153.772 | 105.8225 | −0.0212
Exponential 3 | 0.702156 | 0.204474 | 90.30213 | 168.4422 | 106.2748 | 0.001301
Exponential 4 | 0.896578 | 0.204474 | 88.37423 | 153.7727 | 105.8231 | −0.02121
Exponential 5 | NA | 0.204474 | 92.30211 | 168.1679 | 30.68698 | 0.001229
Hill | NA | 0.204474 | 92.28508 | 40.32119 | 31.54188 | 0.000759
Polynomial (Poly 3) | 0.690261 | 0.204474 | 90.3147 | 175.8228 | 109.4569 | 0.000354
Polynomial (Poly 2) | 0.69227 | 0.204474 | 90.31254 | 173.1861 | 109.4699 | 0.000719
Power | 0.701613 | 0.204474 | 90.3027 | 169.0362 | 109.5006 | 0.000962
Linear | 0.900552 | 0.204474 | 88.36539 | 155.595 | 109.1493 | −0.01798

Bold row indicates the selected model and values.

Figure B-7 Dose response curve for the Linear model fit to red blood cells in female rats (Klaunig et al., 2015)

X-axis is dose (mg/kg-d), and y-axis is mean level of red blood cells (million/µL).

Figure B-7, dose response curve

## B.11 RED BLOOD CELLS—MALE RATS (CHENGELIS ET AL., 2009B)

Table B-14 Dose response data for red blood cells in male rats (Chengelis et al., 2009b)

Dose (mg/kg-d) | Number of animals | Mean (million/µL) | Standard deviation
0 | 10 | 8.89 | 0.32
10 | 10 | 8.84 | 0.281
50 | 10 | 8.88 | 0.69
200 | 10 | 8.17 | 0.593

Table B-15 Benchmark dose results for red blood cells in male rats—non-constant variance, BMR = 1 standard deviation (Chengelis et al., 2009b)

Model | Goodness of fit (p-value) | Test 3 (p-value) | AIC | 1 SD | | Scaled residual for dose group near BMD
Model | Goodness of fit (p-value) | Test 3 (p-value) | AIC | BMD | BMDL | Scaled residual for dose group near BMD
Exponential 2 | 0.211487 | 0.046614 | 60.49036 | 113.155 | 66.64235 | 0.93824
Exponential 3 | 0.211488 | 0.046614 | 60.49034 | 113.324 | 66.64082 | 0.936908
Exponential 4 | 0.112482 | 0.046614 | 61.90217 | 63.88893 | 16.43649 | 1.512764
Exponential 5 | 0.123707 | 0.046614 | 61.75292 | 51.86424 | 17.01699 | 1.668664
Hill | NA | 0.046614 | 61.38555 | 49.50692 | 16.01355 | 1.522475
Polynomial (Poly 3) | 0.208929 | 0.046614 | 60.51469 | 115.2832 | 69.56043 | 0.914633
Polynomial (Poly 2) | 0.208929 | 0.046614 | 60.51469 | 115.2939 | 69.56068 | 0.914397
Power | 0.208929 | 0.046614 | 60.51469 | 115.2866 | 69.56292 | 0.914574
Linear | 0.208929 | 0.046614 | 60.51469 | 115.2954 | 69.55948 | 0.914492

Both constant and nonconstant variance models failed to model the variance data.

Figure B-8 Dose response data for red blood cells in male rats (Chengelis et al., 2009b)

X-axis is dose (mg/kg-d), and y-axis is mean level of red blood cells (million/µL).

Figure B-8, dose response data

## B.12 RED BLOOD CELLS—FEMALE RATS (CHENGELIS ET AL., 2009B)

Table B-16 Dose response data for red blood cells in female rats (Chengelis et al., 2009b)

Dose (mg/kg-d) | Number of animals | Mean (million/µL) | Standard deviation
0 | 10 | 8.62 | 0.338
10 | 10 | 8.53 | 0.696
50 | 10 | 8.32 | 0.491
200 | 10 | 7.93 | 0.43

Table B-17 Benchmark dose results for red blood cells in female rats—constant variance, BMR = 1 standard deviation (Chengelis et al., 2009b)

Model | Goodness of fit (p-value) | Test 2 (p-value) | AIC | 1 SD | | Scaled residual for dose group near BMD
Model | Goodness of fit (p-value) | Test 2 (p-value) | AIC | BMD | BMDL | Scaled residual for dose group near BMD
Exponential 2 | 0.819031 | 0.13452 | 61.22185 | 145.9541 | 94.47522 | 0.13169
Exponential 3 | 0.819031 | 0.13452 | 61.22185 | 145.9541 | 94.47455 | 0.13169
Exponential 4 | 0.828537 | 0.13452 | 62.86949 | 112.0384 | 27.37312 | −0.13653
Exponential 5 | 0.527493 | 0.13452 | 63.2218 | 145.9511 | 16.32358 | 0.131694
Hill | NA | 0.13452 | 64.90674 | 95.16729 | 22.04822 | 0.034663
Polynomial Degree 3 | 0.805881 | 0.13452 | 61.25422 | 148.2376 | 97.83829 | 0.128637
Polynomial Degree 2 | 0.805881 | 0.13452 | 61.25422 | 148.2285 | 97.83846 | 0.128826
Power | 0.805881 | 0.13452 | 61.25422 | 148.2268 | 97.80444 | 0.128858
Linear | 0.805881 | 0.13452 | 61.25422 | 148.2178 | 97.81736 | 0.129033

Bold row indicates the selected model and values.

Figure B-9 Dose response curve for the Exponential 5 model fit to red blood cells in female rats (Chengelis et al., 2009b)

X-axis is dose (mg/kg-d), and y-axis is mean level of red blood cells (million/µL).

Figure B-9, dose response curve

## B.13 RED BLOOD CELLS—MALE RATS (LOVELESS ET AL., 2009)

Table B-18 Dose response data for red blood cells in male rats (Loveless et al., 2009)

Dose (mg/kg-d) | Number of animals | Mean (million/µL) | Standard deviation
0 | 10 | 8.89 | 0.36
20 | 10 | 8.95 | 0.34
100 | 10 | 8.46 | 0.41
500 | 10 | 6.09 | 1.27

Table B-19 Benchmark dose results for red blood cells in male rats—non-constant variance, BMR = 1 standard deviation (Loveless et al., 2009)

Model | Goodness of fit (p-value) | Test 3 (p-value) | AIC | 1 SD | | Scaled residual for dose group near BMD
Model | Goodness of fit (p-value) | Test 3 (p-value) | AIC | BMD | BMDL | Scaled residual for dose group near BMD
Exponential 2 | 0.281567 | 0.991476 | 64.79171 | 52.64163 | 38.9282 | 0.746143
Exponential 3 | 0.376218 | 0.991476 | 65.03997 | 78.0673 | 43.76706 | −0.23387
Exponential 4 | 0.281572 | 0.991476 | 64.79167 | 52.63495 | 38.92813 | 0.744847
Exponential 5 | NA | 0.991476 | 66.45382 | 91.34257 | 46.77432 | −0.01779
Hill | NA | 0.991476 | 66.44302 | 97.70618 | 94.33382 | −0.01642
Polynomial (Poly 3) | 0.291705 | 0.991476 | 65.36868 | 73.55976 | 45.76816 | −0.24307
Polynomial (Poly 2) | 0.291695 | 0.991476 | 65.36872 | 73.60792 | 45.76059 | −0.24304
Power | 0.341547 | 0.991476 | 65.16156 | 77.54244 | 46.28623 | −0.27696
Linear | 0.445951 | 0.991476 | 63.87203 | 59.08585 | 44.57007 | 0.743535

Bold row indicates the selected model and values.

Figure B-10 Dose response curve for the Linear model fit to red blood cells in male rats (Loveless et al., 2009)

X-axis is dose (mg/kg-d), and y-axis is mean level of red blood cells (million/µL).

Figure B-10, dose-response curve

## B.14 RED BLOOD CELLS—FEMALE RATS (LOVELESS ET AL., 2009)

Table B-20 Dose response data for red blood cells in female rats (Loveless et al., 2009)

Dose (mg/kg-d) | Number of animals | Mean (million/µL) | Standard deviation
0 | 10 | 8.34 | 0.43
20 | 10 | 8.53 | 0.52
100 | 10 | 8.32 | 0.27
500 | 9 | 6.85 | 0.63

Table B-21 Benchmark dose results for red blood cells in female rats—constant variance, BMR = 1 standard deviation (Loveless et al., 2009)

Model | Goodness of fit (p-value) | Test 2 (p-value) | AIC | 1 SD | | Scaled residual for dose group near BMD
Model | Goodness of fit (p-value) | Test 2 (p-value) | AIC | BMD | BMDL | Scaled residual for dose group near BMD
Exponential 2 | 0.21884 | 0.087567 | 57.58768 | 133.0328 | 102.9324 | 1.002642
Exponential 3 | 0.331861 | 0.087567 | 57.49047 | 238.0109 | 116.9504 | −0.08346
Exponential 4 | 0.21884 | 0.087567 | 57.58768 | 133.0037 | 102.9322 | 1.002848
Exponential 5 | 0.331861 | 0.087567 | 57.49047 | 238.0095 | 116.9523 | −0.08345
Hill | NA | 0.087567 | 59.42671 | 113.2878 | 101.18 | −2.4 × 10^−06^
Polynomial Degree 3 | 0.320732 | 0.087567 | 57.53481 | 261.7164 | 122.0763 | −0.18275
Polynomial Degree 2 | 0.320735 | 0.087567 | 57.5348 | 261.8718 | 122.0761 | −0.1845
Power | 0.330478 | 0.087567 | 57.49587 | 243.0686 | 122.3971 | −0.09028
Linear | 0.268591 | 0.087567 | 57.17798 | 142.5548 | 112.3638 | 0.87655

Bold row indicates the selected model and values.

Figure B-11 Dose response curve for the Linear model fit to red blood cells in female rats (Loveless et al., 2009)

X-axis is dose (mg/kg-d), and y-axis is mean level of red blood cells (million/µL).

Figure B-11, dose response curve

## B.15 HEPATOCELLULAR NECROSIS—FEMALE RATS (KLAUNIG ET AL., 2015)

Table B-22 Dose response data for hepatocellular necrosis in female rats (Klaunig et al., 2015)

Dose (mg/kg-d) | Number of animals | Incidence | Percentage of incidence
0 | 60 | 2 | 3
10 | 60 | 0 | 0
50 | 60 | 3 | 5
200 | 70 | 12 | 17

The NOAEL was selected over the modeled data. This was based on dose spacing (5, 10, and 50 mg/kg-d) that was closer to 0 than the dose at which an effect was observed (LOAEL = 200 mg/kg-d). The NOAEL of 50 mg/kg-day is more health protective than the BMDL of ^~^100 mg//kg/d and therefore chosen over modeled data.

Figure B-12 Dose response data for hepatocellular necrosis in female rats (Klaunig et al., 2015)

X-axis is dose (mg/kg-d), and y-axis is percent incidence.

Figure B-12, dose response data

## B.16 HEPATOCELLULAR HYPERTROPHY—FEMALE RATS (LOVELESS ET AL., 2009)

Table B-23 Dose response data for hepatocellular hypertrophy in female rats (Loveless et al., 2009)

Dose (mg/kg-d) | Number of animals | Incidence | Percentage of incidence
0 | 10 | 0 | 0
20 | 10 | 0 | 0
100 | 11 | 0 | 0
500 | 10 | 5 | 50

This data set is not considered appropriate for BMD modeling. The response in the high dose group (50%) is much larger than the BMR and there was no response in all other dose groups.

Figure B-13 Dose response data for hepatocellular hypertrophy in female rats (Loveless et al., 2009)

X-axis is dose (mg/kg-d), and y-axis is percent incidence.

Figure B-13, dose response data

## B.17 HEPATOCELLULAR HYPERTROPHY—MALE RATS (LOVELESS ET AL., 2009)

Table B-24 Dose response data for hepatocellular hypertrophy in male rats (Loveless et al., 2009)

Dose (mg/kg-d) | Number of animals | Incidence | Percentage of incidence
0 | 10 | 0 | 0
20 | 10 | 0 | 0
100 | 10 | 4 | 40
500 | 10 | 10 | 100

Table B-25 Benchmark dose results for hepatocellular hypertrophy in male rats—nested model BMR = 10% extra risk (Loveless et al., 2009)

Model | Goodness of fit (p-value) | AIC | 10% Extra risk | | Scaled residual for dose group near BMD
Model | Goodness of fit (p-value) | AIC | BMD | BMDL | Scaled residual for dose group near BMD
Dichotomous Hill | 1 | 17.46023 | 85.47371 | 28.3855 | −1.1 × 10^−06^
Gamma | 0.999944 | 17.46046 | 70.57884 | 20.71965 | 0.00025
Log-Logistic | 1 | 15.46023 | 85.49796 | 28.38513 | 2.91 × 10^−07^
Multistage Degree 3 | 0.997823 | 15.54154 | 59.28867 | 16.83509 | −0.20131
Multistage Degree 2 | 0.902071 | 17.8587 | 46.58058 | 16.60448 | −0.44287
Multistage Degree 1 | 0.391117 | 20.9779 | 18.16542 | 10.6581 | −1.10904
Weibull | 0.987025 | 17.51174 | 62.10697 | 19.73504 | 0.025832
Logistic | 0.999997 | 17.46024 | 89.81641 | 41.88635 | 4.78 × 10^−05^
Log-Probit | 1 | 17.46023 | 78.71963 | 26.71976 | −7.5 × 10^−12^
Probit | 0.999765 | 15.47853 | 71.58692 | 37.71366 | 0.012573

Bold row indicates the selected model and values.

Figure B-14 Dose response curve for the Multistage Degree 1 model fit to hepatocellular hypertrophy in male rats (Loveless et al., 2009)

X-axis is dose (mg/kg-d), and y-axis is percent incidence.

Figure B-14, dose response curve

## B.18 POSTNATAL (F_1_) COMBINED RAT BODY WEIGHT ON PND 0 (LOVELESS ET AL., 2009)

Table B-26 Dose response data for postnatal (F_1_) combined rat body weight on PND 0 (Loveless et al., 2009)

Dose (mg/kg-d) | Number of animals | Mean (g) | Standard deviation
0 | 20 | 7.1 | 0.9
20 | 20 | 6.8 | 0.6
100 | 20 | 6.3 | 0.4
500 | 20 | 5.8 | 0.4

Table B-27 Benchmark dose results for postnatal (F_1_) combined rat body weight on PND 0—non-constant variance, BMR = 5% relative deviation (Loveless et al., 2009)

Model | Goodness of fit (p-value) | Test 3 (p-value) | AIC | 5% relative deviation | | Scaled residual for dose group near BMD
Model | Goodness of fit (p-value) | Test 3 (p-value) | AIC | BMD | BMDL | Scaled residual for dose group near BMD
Exponential 2 | 0.000613 | 0.257697 | 150.4828 | 154.17 | 126.6598 | −2.10808
Exponential 3 | 0.000613 | 0.257697 | 150.4828 | 154.2311 | 126.6606 | −2.10618
Exponential 4 | 0.417875 | 0.257697 | 138.3442 | 28.86879 | 18.04413 | −0.30628
Exponential 5 | 0.417869 | 0.257697 | 138.3442 | 28.89287 | 18.02549 | −0.3069
Hill | 0.721731 | 0.257697 | 137.8148 | 20.37779 | 10.61916 | 0.013748
Polynomial (Poly 3) | 0.000461 | 0.257697 | 151.0527 | 164.7639 | 137.82 | −2.14368
Polynomial (Poly 2) | 0.000461 | 0.257697 | 151.0527 | 164.763 | 137.8213 | −2.144
Power | 0.000461 | 0.257697 | 151.0527 | 164.7277 | 137.8381 | −2.14471
Linear | 0.000461 | 0.257697 | 151.0527 | 164.7482 | 137.8256 | −2.14516

Bold row indicates the selected model and values.

Figure B-15 Dose response curve for the Hill model fit to postnatal (F_1_) combined rat body weight on PND 0 (Loveless et al., 2009)

X-axis is dose (mg/kg-d), and y-axis is mean body weight (g).

Figure B-15, dose response curve

## B.19 POSTNATAL (F_1_) COMBINED MOUSE BODY WEIGHT (PHASE 2) ON PND 0 (IWAI AND HOBERMAN, 2014)

Table B-28 Dose response data for postnatal (F_1_) combined mouse body weight (phase 2) on PND 0 (Iwai and Hoberman, 2014)

Dose (mg/kg-d) | Number of litters | Mean (g) | Standard deviation
0 | 20 | 1.562 | 0.120
7 | 17 | 1.561 | 0.119
35 | 19 | 1.579 | 0.115
175 | 20 | 1.447 | 0.180

Table B-29 Benchmark dose results for postnatal (F_1_) combined mouse body weight (phase 2) on PND 0—constant variance, BMR = 5% relative deviation (Iwai and Hoberman, 2014)

Model | Goodness of fit (p-value) | Test 2 (p-value) | AIC | 5% Relative deviation | | Scaled residual for dose group near BMD
Model | Goodness of fit (p-value) | Test 2 (p-value) | AIC | BMD | BMDL | Scaled residual for dose group near BMD
Exponential 2 | 0.5476652 | 0.11356 | −83.22986065 | 110.1988 | 72.6152 | −0.18098
Exponential 3 | 0.6427413 | 0.11356 | −82.21886799 | 162.9802 | 78.154 | −0.00108
Exponential 4 | 0.5476662 | 0.11356 | −83.22986423 | 110.2315 | 72.6152 | −0.18210
Exponential 5 | 0.6427936 | 0.11356 | −82.21893566 | 163.6378 | 78.15859 | −0.00024
Hill | NA | 0.11356 | −80.21900716 | 80.26504 | 36.86639 | 0.37613
Polynomial (Poly 3) | 0.971011 | 0.11356 | −86.19475647 | 151.5619 | 80.06441 | −0.00309
Polynomial (Poly 2) | 0.8402282 | 0.11356 | −84.08587922 | 140.6661 | 79.398 | −0.018554
Power | 0.6428503 | 0.11356 | −82.21900901 | 172.0405 | 121.5756 | 2.26045 × 10^−05^
Linear | 0.5601161 | 0.11356 | −83.27482038 | 111.6004 | 75.16344 | −0.16700

Bold row indicates the selected model and values.

Figure B-16 Dose response curve for the Polynomial Degree 3 model fit to postnatal (F_1_) combined rat body weight (phase 2) on PND 0 (Iwai and Hoberman, 2014)

X-axis is dose (mg/kg-d), and y-axis is mean body weight (g).

Figure B-16, dose response curve

## B.20 POSTNATAL (F_1_) COMBINED MOUSE BODY WEIGHT (PHASE 1) ON PND 0 (IWAI AND HOBERMAN, 2014)

Table B-30 Dose response data for postnatal (F_1_) combined mouse body weight (phase 1) on PND 0 (Iwai and Hoberman, 2014)

Dose (mg/kg-d) | Number of litters | Mean (g) | Standard deviation
0 | 19 | 1.597 | 0.166
100 | 19 | 1.484 | 0.100
350 | 19 | 1.365 | 0.237
500 | 13 | 1.396 | 0.187

Table B-31 Benchmark dose results for postnatal (F_1_) combined mouse body weight (phase 1) on PND 0—non-constant variance, BMR = 5% relative deviation (Iwai and Hoberman, 2014)

Model | Goodness of fit (p-value) | Test 3 (p-value) | AIC | 5% relative deviation | | Scaled residual for dose group near BMD
Model | Goodness of fit (p-value) | Test 3 (p-value) | AIC | BMD | BMDL | Scaled residual for dose group near BMD
Exponential 2 | 0.1454254 | 0.01314 | −38.99028302 | 153.0166 | 106.9649 | −0.9649
Exponential 3 | 0.1454276 | 0.01314 | −38.99031401 | 152.9732 | 106.9641 | −0.9649
Exponential 4 | 0.0502847 | 0.01314 | −37.01452559 | 152.2536 | 22.05564 | −0.9633
Exponential 5 | NA | 0.01314 | −38.08812965 | 101.2731 | 78.25327 | −0.6831
Hill | NA | 0.01314 | −38.08803429 | 100.2818 | 93.46723 | −0.6814
Polynomial (Poly 3) | 0.1237777 | 0.01314 | −38.66793064 | 163.1923 | 116.9646 | −0.9923
Polynomial (Poly 2) | 0.1237777 | 0.01314 | −38.66793064 | 163.1927 | 116.9612 | −0.9923
Power | 0.1237777 | 0.01314 | −38.66793064 | 163.1924 | 116.9832 | −0.9923
Linear | 0.1237777 | 0.01314 | −38.66793064 | 163.1923 | 117.1098 | −0.9923

Both constant and nonconstant models failed to model the variance data.

Figure B-17 Dose response data for postnatal (F1) combined rat body weight (phase 1) on PND 0 (Iwai and Hoberman, 2014)

X-axis is dose (mg/kg-d), and y-axis is mean body weight (g).

Figure B-17, dose response data

## B.21 POSTNATAL (F_1_) COMBINED MOUSE BODY WEIGHT (PHASES 1 AND 2) ON PND 0 (IWAI AND HOBERMAN, 2014)

Table B-32 Dose response data for postnatal (F_1_) combined mouse body weight (phases 1 and 2) on PND 0 (Iwai and Hoberman, 2014)

Dose (mg/kg-d) | Number of litters | Mean (g) | Standard deviation
0 | 27 | 1.577 | 0.154
7 | 17 | 1.561 | 0.119
35 | 19 | 1.579 | 0.115
100 | 19 | 1.484 | 0.1
175 | 20 | 1.447 | 0.18
350 | 19 | 1.365 | 0.237
500 | 13 | 1.396 | 0.187

Table B-33 Benchmark dose results for postnatal (F_1_) combined mouse body weight (phases 1 and 2) on PND 0—non-constant variance, BMR = 5% relative deviation (Iwai and Hoberman, 2014)

Model | Goodness of fit (p-value) | Test 3 (p-value) | AIC | 5% relative deviation | | Scaled residual for dose group near BMD
Model | Goodness of fit (p-value) | Test 3 (p-value) | AIC | BMD | BMDL | Scaled residual for dose group near BMD
Exponential2 | <0.0001 | <0.0001 | −113.7079045 | 142.9071 | 106.0466 | −0.7543
Exponential3 | <0.0001 | <0.0001 | −113.7083052 | 143.1479 | 105.978 | −0.7565
Exponential4 | <0.0001 | <0.0001 | −113.841077 | 96.60292 | 54.95459 | −0.4165
Exponential5 | <0.0001 | <0.0001 | −114.9537952 | 124.9714 | 78.92795 | −1.0491
Hill | <0.0001 | <0.0001 | −114.828486 | 120.2128 | 87.33994 | −0.9886
Polynomial (Poly 6) | <0.0001 | <0.0001 | −113.1738885 | 151.8416 | 120.7674 | −0.8470
Polynomial (Poly 5) | <0.0001 | <0.0001 | −113.1738881 | 151.8497 | 118.5011 | −0.8469
Polynomial (Poly 4) | <0.0001 | <0.0001 | −113.1738881 | 151.8707 | 114.3476 | −0.8473
Polynomial (Poly 3) | <0.0001 | <0.0001 | −113.1738834 | 124.918 | 89.12952 | −0.8474
Polynomial (Poly 2) | <0.0001 | <0.0001 | −113.1738827 | 124.9218 | 89.12984 | −0.8475
Power | <0.0001 | <0.0001 | −113.1738835 | 124.9172 | 89.12881 | −0.8474
Linear | <0.0001 | <0.0001 | −113.1738818 | 124.9413 | 89.12913 | −0.8478

Both constant and nonconstant models failed to model the variance data.

Figure B-18 Dose response data for postnatal (F1) combined rat body weight (phases 1 and 2) on PND 0 (Iwai and Hoberman, 2014)

X-axis is dose (mg/kg-d), and y-axis is mean body weight (g).

Figure B-18, dose response data

## B.22 POSTNATAL (F_1_) COMBINED MOUSE BODY WEIGHT (PHASE 2) ON PND 4 (IWAI AND HOBERMAN, 2014)

Table B-34 Dose response data for postnatal (F_1_) combined mouse body weight (phase 2) on PND 4 (Iwai and Hoberman, 2014)

Dose (mg/kg-d) | Number of litters | Mean (g) | Standard deviation
0 | 20 | 2.844 | 0.307
7 | 16 | 2.850 | 0.320
35 | 19 | 2.976 | 0.335
175 | 20 | 2.726 | 0.442

Table B-35 Benchmark dose results for postnatal (F_1_) combined mouse body weight (phase 2) on PND 4—constant variance, BMR = 5% relative deviation (Iwai and Hoberman, 2014)

Model | Goodness of fit (p-value) | Test 2 (p-value) | AIC | 5% relative deviation | | Scaled residual for dose group near BMD
Model | Goodness of fit (p-value) | Test 2 (p-value) | AIC | BMD | BMDL | Scaled residual for dose group near BMD
Exponential2 | 0.2719642 | 0.3216 | 62.91273812 | 169.116 | 79.86226 | −0.259556406
Exponential3 | 0.1915765 | 0.3216 | 64.01402032 | 171.7121 | 88.6223 | 0.000775748
Exponential4 | 0.2719642 | 0.3216 | 62.91273812 | 169.1154 | 79.86194 | −0.259556232
Exponential5 | 0.1915772 | 0.3216 | 64.01401491 | 171.7578 | 88.62246 | 0.000965695
Hill | 0.191581 | 0.3216 | 64.01398562 | 90.59589 | 37.60928 | 1.049750693
Polynomial (poly 3) | 0.6280973 | 0.3216 | 60.04847961 | 167.4876 | 89.7897 | −0.008262428
Polynomial (poly 2) | 0.3908438 | 0.3216 | 62.1874628 | 164.7988 | 88.29103 | −0.042810195
Power | 0.1915812 | 0.3216 | 64.01398451 | 174.0668 | 106.2633 | 4.3382 × 10^−06^
Linear | 0.2746896 | 0.3216 | 62.89279543 | 168.0092 | 81.96061 | −0.247433913

Bold row indicates the selected model and values.

Figure B-19 Dose response curve for the Polynomial model (poly 3) fit to postnatal (F1) combined rat body weight (phase 2) on PND 4 (Iwai and Hoberman, 2014)

X-axis is dose (mg/kg-d), and y-axis is mean body weight (g).

Figure B-19, dose response curve

## B.23 POSTNATAL (F_1_) COMBINED MOUSE BODY WEIGHT (PHASE 1) ON PND 4 (IWAI AND HOBERMAN, 2014)

Table B-36 Dose response data for postnatal (F_1_) combined mouse body weight (phase 1) on PND 4 (Iwai and Hoberman, 2014)

Dose (mg/kg-d) | Number of litters | Mean (g) | Standard deviation
0 | 18 | 2.966 | 0.460
100 | 19 | 2.771 | 0.248
350 | 17 | 2.256 | 0.650
500 | 11 | 2.382 | 0.482

Table B-37 Benchmark dose results for postnatal (F_1_) combined mouse body weight (phase 1) on PND 4—non-constant variance, BMR = 5% relative deviation (Iwai and Hoberman, 2014)

Model | Goodness of fit (p-value) | Test 3 (p-value) | AIC | 5% relative deviation | | Scaled residual for dose group near BMD
Model | Goodness of fit (p-value) | Test 3 (p-value) | AIC | BMD | BMDL | Scaled residual for dose group near BMD
Exponential2 | 0.0805287 | 0.01040 | 90.85546713 | 84.46765 | 60.74916 | −0.0400
Exponential3 | 0.0805258 | 0.01040 | 90.85553976 | 84.40685 | 60.76206 | −0.0404
Exponential4 | 0.0358662 | 0.01040 | 92.22063699 | 59.93938 | 28.42237 | 0.3237
Exponential5 | NA | 0.01040 | 90.99580479 | 113.1456 | 55.45824 | −0.6168
Hill | NA | 0.01040 | 90.99580314 | 102.7811 | 95.12445 | −0.6171
Polynomial (poly 3) | 0.064938 | 0.01040 | 91.28582701 | 94.9049 | 70.88712 | −0.1219
Polynomial (poly 2) | 0.064938 | 0.01040 | 91.28582701 | 94.90514 | 70.88731 | −0.1219
Power | 0.064938 | 0.01040 | 91.28582692 | 94.90368 | 70.88898 | −0.1219
Linear | 0.064938 | 0.01040 | 91.28582698 | 94.90395 | 70.88785 | −0.1220

Figure B-20 Dose response data for postnatal (F1) combined rat body weight (phase 1) on PND 4 (Iwai and Hoberman, 2014)

X-axis is dose (mg/kg-d), and y-axis is mean body weight (g).

Figure B-20, dose response data

## B.24 POSTNATAL (F_1_) COMBINED MOUSE BODY WEIGHT (PHASES 1 AND 2) ON PND 4 (IWAI AND HOBERMAN, 2014)

Table B-38 Dose response data for postnatal (F_1_) combined mouse body weight (phase 1) on PND 4 (Iwai and Hoberman, 2014)

Dose (mg/kg-d) | Number of litters | Mean (g) | Standard deviation
0 | 38 | 2.902 | 0.387
7 | 16 | 2.85 | 0.320
35 | 19 | 2.976 | 0.335
100 | 19 | 2.771 | 0.248
175 | 20 | 2.726 | 0.442
350 | 17 | 2.256 | 0.650
500 | 11 | 2.382 | 0.482

Table B-39 Benchmark dose results for postnatal (F_1_) combined mouse body weight (phases 1 and 2) on PND 4—non-constant variance, BMR = 5% relative deviation (Iwai and Hoberman, 2014)

Model | Goodness of fit (p-value) | Test 3 (p-value) | AIC | 5% relative deviation | | Scaled residual for dose group near BMD
Model | Goodness of fit (p-value) | Test 3 (p-value) | AIC | BMD | BMDL | Scaled residual for dose group near BMD
Exponential2 | 0.1128908 | 0.2000 | 147.7836654 | 96.26436 | 71.43879 | −0.0186
Exponential3 | 0.0802807 | 0.2000 | 149.2060003 | 120.9626 | 73.66277 | −0.3003
Exponential4 | 0.1128924 | 0.2000 | 147.7836603 | 96.26532 | 71.43823 | −0.0189
Exponential5 | 0.4079141 | 0.2000 | 145.7744096 | 155.2176 | 102.9449 | 0.4071
Hill | 0.3365496 | 0.2000 | 146.2553381 | 167.5058 | 144.5742 | 0.2848
Polynomial (poly 6) | 0.110707 | 0.2000 | 147.8372526 | 103.2872 | 78.92902 | −0.0985
Polynomial (poly 5) | 0.110707 | 0.2000 | 147.8372543 | 103.3039 | 78.96729 | −0.0986
Polynomial (poly 4) | 0.110707 | 0.2000 | 147.8372526 | 103.2829 | 78.85834 | −0.0984
Polynomial (poly 3) | 0.110707 | 0.2000 | 147.8372498 | 103.2662 | 78.84649 | −0.0983
Polynomial (poly 2) | 0.110707 | 0.2000 | 147.8372526 | 103.2867 | 78.85151 | −0.0985
Power | 0.0672452 | 0.2000 | 149.6433133 | 118.4167 | 79.55287 | −0.2561
Linear | 0.110707 | 0.2000 | 147.8372526 | 103.2844 | 78.84044 | −0.0985

Bold row indicates the selected model and values.

Figure B-21 Dose response curve for the Exponential 5 model fit to postnatal (F1) combined mouse body weight (phases 1 and 2) on PND 4 (Iwai and Hoberman, 2014)

X-axis is dose (mg/kg-d), and y-axis is mean body weight (g).

Figure B-21, dose response curve

## B.25 PERINATAL MORTALITY (PHASE 2) ON PND 0–21 (IWAI AND HOBERMAN, 2014)

Table B-40 Nested model summary for perinatal mortality (phase 2) on PND 0–21, BMR = 1% extra risk (Iwai and Hoberman, 2014)

Model type | Litter-specific covariate | Intralitter correlation | Goodness of fit (p-value) | AIC | BMD | BMDL
Nested Logistic | Yes | Yes | 0.223 | 145.10 | 150.6 | 24.50
Nested Logistic | Yes | No | 0.0037 | 158.29 | 157.6 | 39.26
Nested Logistic | No | Yes | 0.2113 | 141.20 | 151.4 | 24.77
Nested Logistic | No | No | 0.003 | 154.50 | 158.0 | 39.03

Nested Logistic model with intralitter correlation is selected as the best model based on the lowest AIC value.

Bold row indicates the selected model and values.

Figure B-22 Dose response curve for the Nested National Center for Toxicological Research model fit to perinatal mortality (phase 2) on PND 0–21 (Iwai and Hoberman, 2014)

X-axis is dose (mg/kg-d), and y-axis is mortality.

Figure B-22, dose response curve

## B.26 PERINATAL MORTALITY (PHASE 1) ON PND 0–21 (IWAI AND HOBERMAN, 2014)

Table B-41 Nested model summary for perinatal mortality (phase 1) on PND 0–21, BMR = 1% extra risk (Iwai and Hoberman, 2014)

Model type | Litter-specific covariate | Intralitter correlation | Goodness of fit (p-value) | AIC | BMD | BMDL
Nested Logistic | Yes | Yes | 0.053 | 356.23 | 206.1 | 105.8
Nested Logistic | Yes | No | <0.0001 | 478.37 | 238.9 | 177.2
Nested Logistic | No | Yes | 0.0593 | 353.33 | 201.7 | 98.61
Nested Logistic | No | No | <0.0001 | 477.04 | 233.1 | 162.7

The means of the data cannot be modeled (all goodness of fit p-value > 0.1) for phase 1 data; the data is not amenable to BMD modeling.

Figure B-23 Dose response data perinatal mortality (phase 1) on PND 4 (Iwai and Hoberman, 2014)

X-axis is dose (mg/kg-d), and y-axis is percent incidence.

Figure B-23, dose response data

## B.27 PERINATAL MORTALITY (PHASES 1 AND 2) ON PND 0–21 (IWAI AND HOBERMAN, 2014)

Table B-42 Nested model summary for perinatal mortality (phases 1 and 2) on PND 0–21, BMR = 1% extra risk (Iwai and Hoberman, 2014)

Model type | Litter-specific covariate | Intralitter correlation | Goodness of fit (p-value) | AIC | BMD | BMDL
Nested Logistic | Yes | Yes | 0.024 | 495.44 | 150.9 | 85.15
Nested Logistic | Yes | No | <0.0001 | 632.14 | 199.7 | 138.2
Nested Logistic | No | Yes | 0.029 | 491.80 | 147.7 | 83.59
Nested Logistic | No | No | <0.0001 | 629.52 | 195.2 | 134.0

The means of the data cannot be modeled (all goodness of fit p-value > 0.1) for phases 1and 2 data; the data is not amenable to BMD modeling.

Figure B-24 Dose response data perinatal mortality (phases 1 and 2) on PND 0–21 (Iwai and Hoberman, 2014)

X-axis is dose (mg/kg-d), and y-axis is percent incidence.

Figure B-24, dose response data

## B.28 TOTAL THYROXINE (T4) IN MALE RATS - (NTP, 2018)

Table B-43 Dose response data for thyroxine (T4) in male rats (NTP, 2018)

Dose (mg/kg-d) | Number of animals | Mean (g) | Standard deviation
0 | 10 | 4.26 | 0.461692538
62.5 | 10 | 3.4 | 0.730486139
125 | 9 | 2.933 | 0.483
250 | 10 | 2.9 | 0.521775814
500 | 10 | 2.37 | 0.322552321
1,000 | 10 | 1.77 | 0.547074035

Table B-44 Benchmark dose results for total thyroxine (T4) in male rats—constant variance, BMR = 1 standard deviation (NTP, 2018)

Model | Goodness of fit (p-value) | Test 2 (p-value) | AIC | 1 SD | | Scaled residual for dose group near BMD
Model | Goodness of fit (p-value) | Test 2 (p-value) | AIC | BMD | BMDL | Scaled residual for dose group near BMD
Exponential2 | 0.001553 | 0.2402 | 17.8629446 | 145.2153 | 266.23938 | −0.59715
Exponential3 | 0.001553 | 0.2402 | 19.8639886 | 145.2153 | 266.23938 | −0.59715
Exponential4 | 0.028228 | 0.2402 | 17.8629446 | 43.1832 | 131.51922 | −1.09556
Exponential5 | 0.028228 | 0.2402 | 15.9850469 | 43.1832 | 131.51922 | −1.09556
Hill | 0.121780 | 0.2402 | 16.4752017 | 25.96669 | 92.61432 | −0.73657
Polynomial (poly 6) | 0.000100 | 0.2402 | 18.9269281 | 261.7194 | 390.80563 | −1.01211
Polynomial (poly 5) | 0.000100 | 0.2402 | 17.8629446 | 240.1021 | 390.82343 | −1.01211
Polynomial (poly 4) | 0.000100 | 0.2402 | 15.8629568 | 240.1021 | 390.79722 | −1.01211
Polynomial (poly 3) | 0.000100 | 0.2402 | 17.8629446 | 240.1022 | 390.61877 | −1.01211
Polynomial (poly 2) | 0.000100 | 0.2402 | 17.8629436 | 240.1086 | 390.56516 | −1.01211
Power | 0.000100 | 0.2402 | 17.8629446 | 240.1066 | 390.5741 | −1.01211
Linear | 0.001553 | 0.2402 | 19.8639886 | 145.2153 | 266.23938 | −0.59715

Bold row indicates the selected model and values.

Figure B-25 Dose response curve for the Hill model fit to thyroxine (T4) in male rats (NTP, 2018)

X-axis is dose (mg/kg-d), and y-axis is mean level of thyroxine (T4) (µg/dL).

Figure B-25, dose response curve