# APPENDIX A SYSTEMATIC REVIEW PROTOCOL FOR THE PFAS IRIS ASSESSMENTS

A single systematic review protocol was used to guide the development of five separate IRIS PFAS [per- and polyfluoroalkyl substances] assessments (i.e., perfluorobutanoic acid [PFBA], perfluorohexanoic acid [PFHxA], perfluorohexane sulfonate [PFHxS], perfluorononanoic acid [PFNA], and perfluorodecanoic acid [PFDA]). This “Systematic Review Protocol for the PFAS IRIS Assessments” was released for public comment and subsequently updated. The updated protocol and prior versions can be found at the following location: http://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=345065