# REFERENCES

Abe, T; Takahashi, M; Kano, M; Amaike, Y; Ishii, C; Maeda, K; Kudoh, Y; Morishita, T; Hosaka, T; Sasaki, T; Kodama, S; Matsuzawa, A; Kojima, H; Yoshinari, K. (2017). Activation of nuclear receptor CAR by an environmental pollutant perfluorooctanoic acid. Arch Toxicol 91: 2365–2374. 10.1007/s00204-016-1888-3.27832320
Abraham, K; El-Khatib, AH; Schwerdtle, T; Monien, BH. (2021). Perfluorobutanoic acid (PFBA): No high-level accumulation in human lung and kidney tissue. Int J Hyg Environ Health 237: 113830. 10.1016/j.ijheh.2021.113830.34450542
Angrish, MM; Kaiser, JP; Mcqueen, CA; Chorley, BN. (2016). Tipping the balance: Hepatotoxicity and the 4 apical key events of hepatic steatosis [Review]. Toxicol Sci 150: 261–268. 10.1093/toxsci/kfw018.26980302
Antignac, JP; Veyrand, B; Kadar, H; Marchand, P; Oleko, A; Le Bizec, B; Vandentorren, S. (2013). Occurrence of perfluorinated alkylated substances in breast milk of French women and relation with socio-demographical and clinical parameters: Results of the ELFE pilot study. Chemosphere 91: 802–808. 10.1016/j.chemosphere.2013.01.088.23473698
ATSDR (Agency for Toxic Substances and Disease Registry). (2017). Substance priority list (SPL) resource page. Retrieved from https://www.atsdr.cdc.gov/spl/resources/ATSDR_2017_Full_SPL_Spreadsheet.xlsx
ATSDR (Agency for Toxic Substances and Disease Registry). (2018a). An overview of perfluoroalkyl and polyfluoroalkyl substances and interim guidance for clinicians responding to patient exposure concerns. Interim guidance revised 5/7/2018. https://stacks.cdc.gov/view/cdc/77114.
ATSDR (Agency for Toxic Substances and Disease Registry). (2018b). Toxicological profile for perfluoroalkyls. Draft for public comment [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention. https://www.atsdr.cdc.gov/toxprofiles/tp200.pdf.
ATSDR (Agency for Toxic Substances and Disease Registry). (2021). Toxicological profile for perfluoroalkyls [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. 10.15620/cdc:59198.
Bangma, JT; Reiner, J; Fry, RC; Manuck, T; Mccord, J; Strynar, MJ. (2021). Identification of an Analytical Method Interference for Perfluorobutanoic Acid in Biological Samples. Environ Sci Technol Lett 8: 1085–1090. 10.1021/acs.estlett.1c00901.35127964
Bansal, R; Tighe, D; Danai, A; Rawn, DFK; Gaertner, DW; Arnold, DL; Gilbert, ME; Zoeller, RT. (2014). Polybrominated Diphenyl Ether (DE-71) Interferes With Thyroid Hormone Action Independent of Effects on Circulating Levels of Thyroid Hormone in Male Rats. Endocrinology 155: 4104–4112. 10.1210/en.2014-1154.25060363
Bansal, R; Zoeller, RT. (2008). Polychlorinated biphenyls (Aroclor 1254) do not uniformly produce agonist actions on thyroid hormone responses in the developing rat brain. Endocrinology 149: 4001–4008. 10.1210/en.2007-1774.18420739
Bao, S; Zhang, J; Lin, Z; Su, K; Mo, J; Hong, L; Qian, S; Chen, L; Sun, F; Wen, C; Wu, Q; Hu, L; Lin, G; Wang, X. (2017a). Serum metabolic changes in rats after intragastric administration of dextromethorphan. Biomed Chromatogr 31: e3814. 10.1002/bmc.3814.
Bao, WW; Qian, ZM; Geiger, SD; Liu, E; Liu, Y; Wang, SQ; Lawrence, WR; Yang, BY; Hu, LW; Zeng, XW; Dong, GH. (2017b). Gender-specific associations between serum isomers of perfluoroalkyl substances and blood pressure among Chinese: Isomers of C8 Health Project in China. Sci Total Environ 607–608: 1304–1312. 10.1016/j.scitotenv.2017.07.124.
Barton, CA; Kaiser, MA; Russell, MH. (2007). Partitioning and removal of perfluorooctanoate during rain events: the importance of physical-chemical properties. J Environ Monit 9: 839–846. 10.1039/b703510a.17671665
Bassett, JHD; Clement-Lacroix, P; Samarut, J; Chassande, O; Williams, GR; O’Shea, PJ; Sriskantharajah, S; Rabier, B; Boyde, A; Howell, PGT; Weiss, R, oyE; Roux, JP; Malaval, L, uc. (2007). Thyroid hormone excess rather than thyrotropin deficiency induces osteoporosis in hyperthyroidism. Mol Endocrinol 1095–1107. 10.1210/me.2007-0033.
Batt, AM; Ferrari, L. (1995). Manifestations of chemically-induced liver-damage. Clin Chem 41: 1882–1887.7497649
Beggs, KM; Mcgreal, S. R.; Mccarthy, A; Gunewardena, S; Lampe, JN; Lau, C; Apte, U. (2016). The role of hepatocyte nuclear factor 4-alpha in perfluorooctanoic acid- and perfluorooctanesulfonic acid-induced hepatocellular dysfunction. Toxicol Appl Pharmacol 304: 18–29. 10.1016/j.taap.2016.05.001.27153767
Bernal, J. (2015). Thyroid hormones in brain development and function. In LJ De Groot; G Chrousos; K Dungan; KR Feingold; A Grossman; JM Hershman; C Koch; M Korbonits; R McLachlan; M New; J Purnell; R Rebar; F Singer; A Vinik (Eds.), NCBI Bookshelf. South Dartmouth, MA: MDText.com, Inc.
Bizzarro, MJ; Gross, I. (2004). Effects of hormones on fetal lung development [Review]. Obstet Gynecol Clin North Am 31: 949–961, xii. 10.1016/j.ogc.2004.08.001.15550344
Bjork, JA; Wallace, KB. (2009). Structure-Activity Relationships and Human Relevance for Perfluoroalkyl Acid-Induced Transcriptional Activation of Peroxisome Proliferation in Liver Cell Cultures. Toxicol Sci 111: 89–99. 10.1093/toxsci/kfp093.19407336
Blaine, AC; Rich, CD; Hundal, LS; Lau, C; Mills, MA; Harris, KM; Higgins, CP. (2013). Uptake of perfluoroalkyl acids into edible crops via land applied biosolids: field and greenhouse studies. Environ Sci Technol 47: 14062–14069. 10.1021/es403094q.24206563
Buhrke, T; Krüger, E; Pevny, S; Rößler, M; Bitter, K; Lampen, A. (2015). Perfluorooctanoic acid (PFOA) affects distinct molecular signalling pathways in human primary hepatocytes. Toxicology 333: 53–62. 10.1016/j.tox.2015.04.004.25868421
Buist, SC; Cherrington, NJ; Choudhuri, S; Hartley, DP; Klaassen, CD. (2002). Gender-specific and developmental influences on the expression of rat organic anion transporters. J Pharmacol Exp Ther 301: 145–151. 10.1124/jpet.301.1.145.11907168
Burkemper, JL; Aweda, TA; Rosenberg, AJ; Lunderberg, DM; Peaslee, GF; Lapi, SE. (2017). Radiosynthesis and biological distribution of F-18-labeled perfluorinated alkyl substances. Environ Sci Technol Lett 4: 211–215. 10.1021/acs.estlett.7b00042.
Butenhoff, JL; Bjork, JA; Chang, SC; Ehresman, DJ; Parker, GA; Das, K; Lau, C; Lieder, PH; van Otterdijk, FM; Wallace, KB. (2012a). Toxicological evaluation of ammonium perfluorobutyrate in rats: twenty-eight-day and ninety-day oral gavage studies. Reprod Toxicol 33: 513–530. 10.1016/j.reprotox.2011.08.004.21878386
Butenhoff, JL; Chang, SC; Olsen, GW; Thomford, PJ. (2012b). Chronic dietary toxicity and carcinogenicity study with potassium perfluorooctanesulfonate in Sprague Dawley rats. Toxicology 293: 1–15. 10.1016/j.tox.2012.01.003.22266392
Butenhoff, JL; Chang, SC; Olsen, GW; Thomford, PJ. (2012c). Chronic dietary toxicity and carcinogenicity study with potassium perfluorooctanesulfonate in Sprague Dawley rats: Supplemental data. Toxicology 293.
Butenhoff, JL; Kennedy, GL; Frame, S. R.; O’Connor, JC; York, RG. (2004). The reproductive toxicology of ammonium perfluorooctanoate (APFO) in the rat. Toxicology 196: 95–116. 10.1016/j.tox.2003.11.005.15036760
Calvo, R; Obregon, MJ; Ruiz de Ona, C; Ferreiro, B; del Rey, FE; Morreale de escobar, G. (1990). Thyroid hormone economy in pregnant rats near term: a “physiological” animal model of non thyroidal illness. Endocrinology 127: 10–16. 10.1210/endo-127-1-10.2113860
CDC (Centers for Disease Control and Prevention). (2019). Fourth National Report on Human Exposure to Environmental Chemicals, Updated Tables, January 2019, Volume 1. Centers for Disease Control and Prevention, National Health and Nutrition Examination Survey. https://www.cdc.gov/exposurereport/pdf/FourthReport_UpdatedTables_Volume1_Jan2019-508.pdf.
Cerrutti, JA; Brandoni, A; Quaglia, NB; Torres, AM. (2002). Sex differences in p-aminohippuric acid transport in rat kidney: Role of membrane fluidity and expression of OAT1. Mol Cell Biochem 233: 175–179. 10.1023/A:1015563021602.12083373
Chang, S; Butenhoff, JL; Parker, GA; Coder, PS; Zitzow, JD; Krisko, RM; Bjork, JA; Wallace, KB; Seed, JG. (2018). Reproductive and developmental toxicity of potassium perfluorohexanesulfonate in CD-1 mice. Reprod Toxicol 78: 150–168. 10.1016/j.reprotox.2018.04.007.29694846
Chang, S; Das, K; Ehresman, DJ; Ellefson, ME; Gorman, GS; Hart, JA; Noker, PE; Tan, Y; Lieder, PH; Lau, C; Olsen, GW; Butenhoff, JL. (2008). Comparative pharmacokinetics of perfluorobutyrate in rats, mice, monkeys, and humans and relevance to human exposure via drinking water. Toxicol Sci 104: 40–53. 10.1093/toxsci/kfn057.18353799
Chen, YM; Guo, LH. (2009). Fluorescence study on site-specific binding of perfluoroalkyl acids to human serum albumin. Arch Toxicol 83: 255–261. 10.1007/s00204-008-0359-x.18854981
Chengelis, CP; Kirkpatrick, JB; Radovsky, A; Shinohara, M. (2009). A 90-day repeated dose oral (gavage) toxicity study of perfluorohexanoic acid (PFHxA) in rats (with functional observational battery and motor activity determinations). Reprod Toxicol 27: 342–351. 10.1016/j.reprotox.2009.01.006.19429405
Crebelli, R; Caiola, S; Conti, L; Cordelli, E; De Luca, G; Dellatte, E; Eleuteri, P; Iacovella, N; Leopardi, P; Marcon, F; Sanchez, M; Sestili, P; Siniscalchi, E; Villani, P. (2019). Can sustained exposure to PFAS trigger a genotoxic response? A comprehensive genotoxicity assessment in mice after subacute oral administration of PFOA and PFBA. Regul Toxicol Pharmacol 106: 169–177. 10.1016/j.yrtph.2019.05.005.31071380
Crofton, KM. (2004). Developmental disruption of thyroid hormone: Correlations with hearing dysfunction in rats. Risk Anal 24: 1665–1671. 10.1111/j.0272-4332.2004.00557.x.15660619
Crofton, KM; Craft, ES; Hedge, JM; Gennings, C; Simmons, JE; Carchman, RA; Carter, WH, Jr; Devito, MJ. (2005). Thyroid-hormone-disrupting chemicals: Evidence for dose-dependent additivity or synergism. Environ Health Perspect 113: 1549–1554. 10.1289/ehp.8195.16263510
Crofton, KM; Zoeller, RT. (2005). Mode of action: neurotoxicity induced by thyroid hormone disruption during development--hearing loss resulting from exposure to PHAHs [Review]. Crit Rev Toxicol 35: 757–769. 10.1080/10408440591007304.16417043
Das, KP; Grey, BE; Zehr, RD; Wood, CR; Butenhoff, JL; Chang, SC; Ehresman, DJ; Tan, YM; Lau, C. (2008). Effects of perfluorobutyrate exposure during pregnancy in the mouse. Toxicol Sci 105: 173–181. 10.1093/toxsci/kfn099.18511431
Das, KP; Wood, CR; Lin, MT; Starkov, AA; Lau, C; Wallace, KB; Corton, JC; Abbott, BD. (2017). Perfluoroalkyl acids-induced liver steatosis: Effects on genes controlling lipid homeostasis. Toxicology 378: 37–52. 10.1016/j.tox.2016.12.007.28049043
Davies, B; Morris, T. (1993). Physiological parameters in laboratory animals and humans [Review]. Pharm Res 10: 1093–1095. 10.1023/A:1018943613122.8378254
di Masi, A; De Marinis, E; Ascenzi, P; Marino, M. (2009). Nuclear receptors CAR and PXR: Molecular, functional, and biomedical aspects [Review]. Mol Aspects Med 30: 297–343. 10.1016/j.mam.2009.04.002.19427329
Diez, D; Morte, B; Bernal, J. (2021). Single-cell transcriptome profiling of thyroid hormone effectors in the human fetal neocortex: expression of SLCO1C1, DIO2, and THRB in specific cell types. Thyroid 31: 1577–1588. 10.1089/thy.2021.0057.34114484
Espinosa, JS; Stryker, MP. (2012). Development and plasticity of the primary visual cortex [Review]. Neuron 75: 230–249. 10.1016/j.neuron.2012.06.009.22841309
Feng, X; Cao, X; Zhao, S; Wang, X; Hua, X; Chen, L; Chen, L. (2017). Exposure of pregnant mice to perfluorobutanesulfonate causes hypothyroxinemia and developmental abnormalities in female offspring. Toxicol Sci 155: 409–419. 10.1093/toxsci/kfw219.27803384
Finken, MJ; van Eijsden, M; Loomans, EM; Vrijkotte, TG; Rotteveel, J. (2013). Maternal hypothyroxinemia in early pregnancy predicts reduced performance in reaction time tests in 5- to 6-year-old offspring. J Clin Endocrinol Metab 98: 1417–1426. 10.1210/jc.2012-3389.23408575
Foreman, JE; Chang, SC; Ehresman, DJ; Butenhoff, JL; Anderson, CR; Palkar, PS; Kang, BH; Gonzalez, FJ; Peters, JM. (2009). Differential Hepatic Effects of Perfluorobutyrate Mediated by Mouse and Human PPAR-alpha. Toxicol Sci 110: 204–211. 10.1093/toxsci/kfp077.19359353
Forhead, AJ; Fowden, AL. (2014). Thyroid hormones in fetal growth and prepartum maturation [Review]. J Endocrinol 221: R87–R103. 10.1530/JOE-14-0025.24648121
Fu, Y; Wang, T; Fu, Q; Wang, P; Lu, Y. (2014). Associations between serum concentrations of perfluoroalkyl acids and serum lipid levels in a Chinese population. Ecotoxicol Environ Saf 106: 246–252. 10.1016/j.ecoenv.2014.04.039.24863755
Fukuda, H; Ohshima, K; Mori, M; Kobayashi, I; Greer, MA. (1980). Sequential changes in the pituitary-thyroid axis during pregnancy and lactation in the rat. Endocrinology 107: 1711–1716. 10.1210/endo-107-6-1711.7428688
G, MDE; R, C; J, OM; F, EDR. (1990). CONTRIBUTION OF MATERNAL THYROXINE TO FETAL THYROXINE POOLS IN NORMAL RATS NEAR TERM. Endocrinology 126: 2765–2767.2328706
Gebbink, WA; Berger, U; Cousins, IT. (2015). Estimating human exposure to PFOS isomers and PFCA homologues: the relative importance of direct and indirect (precursor) exposure. Environ Int 74: 160–169. 10.1016/j.envint.2014.10.013.25454233
Giera, S; Bansal, R; Ortiz-Toro, TM; Taub, DG; Zoeller, RT. (2011). Individual polychlorinated biphenyl (PCB) congeners produce tissue- and gene-specific effects on thyroid hormone signaling during development. Endocrinology 152: 2909–2919. 10.1210/en.2010-1490.21540284
Gilbert, ME. (2011). Impact of low-level thyroid hormone disruption induced by propylthiouracil on brain development and function. Toxicol Sci 124: 432–445. 10.1093/toxsci/kfr244.21964421
Gilbert, ME; Ramos, RL; Mccloskey, DP; Goodman, JH. (2014). Subcortical band heterotopia in rat offspring following maternal hypothyroxinaemia: Structural and functional characteristics. J Neuroendocrinol 26: 528–541. 10.1111/jne.12169.24889016
Gilbert, ME; Sanchez-Huerta, K; Wood, C. (2016). Mild thyroid hormone insufficiency during development compromises activity-dependent neuroplasticity in the hippocampus of adult male rats : Supplemental data [Supplemental Data]. Endocrinology 157: 774–787.26606422
Gilbert, ME; Sui, L. (2008). Developmental exposure to perchlorate alters synaptic transmission in hippocampus of the adult rat. Environ Health Perspect 116: 752–760. 10.1289/ehp.11089.18560531
Gilbert, ME; Zoeller, RT. (2010). Thyroid hormones--impact on the developing brain: Possible mechanisms of neurotoxicity. In GJ Harry; HA Tilson (Eds.), Neurotoxicology (3rd ed., pp. 79–111). New York, NY: Informa Healthcare.
Gomis, MI; Vestergren, R; Borg, D; Cousins, IT. (2018). Comparing the toxic potency in vivo of long-chain perfluoroalkyl acids and fluorinated alternatives. Environ Int 113: 1–9. 10.1016/j.envint.2018.01.011.29421396
Grandjean, P; Timmermann, CAG; Kruse, M; Nielsen, F; Vinholt, PJ; Boding, L; Heilmann, C; Mølbak, K. (2020). Severity of COVID-19 at elevated exposure to perfluorinated alkylates. PLoS ONE 15: e0244815. 10.1371/journal.pone.0244815.33382826
Guyatt, G; Oxman, AD; Akl, EA; Kunz, R; Vist, G; Brozek, J; Norris, S; Falck-Ytter, Y; Glasziou, P; DeBeer, H; Jaeschke, R; Rind, D; Meerpohl, J; Dahm, P; Schünemann, HJ. (2011). GRADE guidelines: 1. Introduction-GRADE evidence profiles and summary of findings tables. J Clin Epidemiol 64: 383–394. 10.1016/j.jclinepi.2010.04.026.21195583
Haddow, JE; Palomaki, GE; Allan, WC; Williams, JR; Knight, GJ; Gagnon, J; O’Heir, CE; Mitchell, ML; Hermos, RJ; Waisbren, SE; Faix, JD; Klein, RZ. (1999). Maternal thyroid deficiency during pregnancy and subsequent neuropsychological development of the child. N Engl J Med 341: 549–555. 10.1056/NEJM199908193410801.10451459
Hall, AP; Elcombe, CR; Foster, JR; Harada, T; Kaufmann, W; Knippel, A; Küttler, K; Malarkey, DE; Maronpot, RR; Nishikawa, A; Nolte, T; Schulte, A; Strauss, V; York, MJ. (2012). Liver hypertrophy: a review of adaptive (adverse and non-adverse) changes--conclusions from the 3rd International ESTP Expert Workshop [Review]. Toxicol Pathol 40: 971–994. 10.1177/0192623312448935.22723046
Hassan, I; El-Masri, H; Kosian, PA; Ford, J; Degitz, SJ; Gilbert, ME. (2017). Neurodevelopment and thyroid hormone synthesis inhibition in the rat: quantitative understanding within the adverse outcome pathway framework. Toxicol Sci 160: 57–73. 10.1093/toxsci/kfx163.28973696
Henrichs, J; Bongers-Schokking, JJ; Schenk, JJ; Ghassabian, A; Schmidt, HG; Visser, TJ; Hooijkaas, H; de Muinck Keizer-Schrama, SM; Hofman, A; Jaddoe, VV; Visser, W; Steegers, EA; Verhulst, FC; de Rijke, YB; Tiemeier, H. (2010). Maternal thyroid function during early pregnancy and cognitive functioning in early childhood: The generation R study. J Clin Endocrinol Metab 95: 4227–4234. 10.1210/jc.2010-0415.20534757
Heo, JJ; Lee, JW; Kim, SK; Oh, JE. (2014). Foodstuff analyses show that seafood and water are major perfluoroalkyl acids (PFAAs) sources to humans in Korea. J Hazard Mater 279: 402–409. 10.1016/j.jhazmat.2014.07.004.25093550
Hill, AB. (1965). The environment and disease: Association or causation? Proc R Soc Med 58: 295–300.14283879
Hillman, NH; Kallapur, SG; Jobe, AH. (2012). Physiology of transition from intrauterine to extrauterine life. Clin Perinatol 39: 769–783.23164177
Hood, A; Hashmi, R; Klaassen, CD. (1999). Effects of microsomal enzyme inducers on thyroid-follicular cell proliferation, hyperplasia, and hypertrophy. Toxicol Appl Pharmacol 160: 163–170. 10.1006/taap.1999.8752.10527915
Hood, A; Klaassen, CD. (2000). Differential effects of microsomal enzyme inducers on in vitro thyroxine (T4) and triiodothyronine (T3) glucuronidation. Toxicol Sci 55: 78–84. 10.1093/toxsci/55.1.78.10788562
Howdeshell, KL. (2002). A model of the development of the brain as a construct of the thyroid system [Review]. Environ Health Perspect 110 Suppl 3: 337–348. 10.1289/ehp.02110s3337.
Hulbert, AJ. (2000). Thyroid hormones and their effects: A new perspective [Review]. Biol Rev Camb Philos Soc 75: 519–631.11117200
Hurley, MD; Andersen, MPS; Wallington, TJ; Ellis, DA; Martin, JW; Mabury, SA. (2004). Atmospheric chemistry of perfluorinated carboxylic acids: Reaction with OH radicals and atmospheric lifetimes. J Phys Chem A 108: 615–620. 10.1021/jp036343b.
Ikeda, T; Aiba, K; Fukuda, K; Tanaka, M. (1985). The induction of peroxisome proliferation in rat liver by perfluorinated fatty acids, metabolically inert derivatives of fatty acids. J Biochem 98: 475–482. 10.1093/oxfordjournals.jbchem.a135302.4066651
IPCS (International Programme on Chemical Safety). (2010). Characterization and application of physiologically based pharmacokinetic models in risk assessment. (Harmonization Project Document No 9). Geneva, Switzerland: World Health Organization. http://www.inchem.org/documents/harmproj/harmproj/harmproj9.pdf.
Jaeschke, H; Lemasters, JJ. (2003). Apoptosis versus oncotic necrosis in hepatic ischemia/reperfusion injury. Gastroenterology 125: 1246–1257. 10.1016/S0016-5085(03)01209-5.14517806
Jansen, TA; Korevaar, TIM; Mulder, TA; White, T; Muetzel, RL; Peeters, RP; Tiemeier, H. (2019). Maternal thyroid function during pregnancy and child brain morphology: a time window-specific analysis of a prospective cohort. Lancet Diabetes Endocrinol 7: 629–637. 10.1016/S2213-8587(19)30153-6.31262704
Joshi-Barve, S; Kirpich, I; Cave, MC; Marsano, LS; McClain, CJ. (2015). Alcoholic, nonalcoholic, and toxicant-associated steatohepatitis: Mechanistic similarities and differences [Review]. CMGH 1: 356–367. 10.1016/j.jcmgh.2015.05.006.28210688
Julvez, J; Alvarez-Pedrerol, M; Rebagliato, M; Murcia, M; Forns, J; Garcia-Esteban, R; Lertxundi, N; Espada, M; Tardon, A; Riano Galan, I; Sunyer, J. (2013). Thyroxine levels during pregnancy in healthy women and early child neurodevelopment. Epidemiology 24: 150–157. 10.1097/EDE.0b013e318276ccd3.23232616
Just, WW; Gorgas, K; Hartl, FU; Heinemann, P; Salzer, M; Schimassek, H. (1989). Biochemical effects and zonal heterogeneity of peroxisome proliferation induced by perfluorocarboxylic acids in rat liver. Hepatology 9: 570–581. 10.1002/hep.1840090411.2925163
Kaiser, JP; Lipscomb, JC; Wesselkamper, SC. (2012). Putative mechanisms of environmental chemical-induced steatosis. Int J Toxicol 31: 551–563. 10.1177/1091581812466418.23197488
Kass, GEN. (2006). Mitochondrial involvement in drug-induced hepatic injury. Chem Biol Interact 163: 145–159. 10.1016/j.cbi.2006.06.007.16889760
Kato, Y; Kuge, K; Kusuhara, H; Meier, PJ; Sugiyama, Y. (2002). Gender difference in the urinary excretion of organic anions in rats. J Pharmacol Exp Ther 302: 483–489. 10.1124/jpet.102.033878.12130705
Kim, DH; Kim, UJ; Kim, HY; Choi, SD; Oh, JE. (2016). Perfluoroalkyl substances in serum from South Korean infants with congenital hypothyroidism and healthy infants - Its relationship with thyroid hormones. Environ Res 147: 399–404. 10.1016/j.envres.2016.02.037.26950028
Kim, SK; Kannan, K. (2007). Perfluorinated acids in air, rain, snow, surface runoff, and lakes: relative importance of pathways to contamination of urban lakes. Environ Sci Technol 41: 8328–8334. 10.1021/es072107t.18200859
Klaunig, JE; Shinohara, M; Iwai, H; Chengelis, CP; Kirkpatrick, JB; Wang, Z; Bruner, RH. (2015). Evaluation of the chronic toxicity and carcinogenicity of perfluorohexanoic acid (PFHxA) in Sprague-Dawley rats. Toxicol Pathol 43: 209–220. 10.1177/0192623314530532.25377447
Kleiner, DE; Makhlouf, HR. (2016). Histology of Nonalcoholic Fatty Liver Disease and Nonalcoholic Steatohepatitis in Adults and Children. Clin Liver Dis 20: 293–+. 10.1016/j.cld.2015.10.011.27063270
Kleiner, DE; Weerasinghe, P; Buja, LM. (2012). Oncosis: An important non-apoptotic mode of cell death. Exp Mol Pathol 93: 302–308. 10.1016/j.yexmp.2012.09.018.23036471
Korevaar, TIM; Muetzel, R; Medici, M; Chaker, L; Jaddoe, VWV; de Rijke, YB; Steegers, EAP; Visser, TJ; White, T; Tiemeier, H; Peeters, RP. (2016). Association of maternal thyroid function during early pregnancy with offspring IQ and brain morphology in childhood: A population-based prospective cohort study. Lancet Diabetes Endocrinol 4: 35–43. 10.1016/S2213-8587(15)00327-7.26497402
Kotthoff, M; Müller, J; Jürling, H; Schlummer, M; Fiedler, D. (2015). Perfluoroalkyl and polyfluoroalkyl substances in consumer products. Environ Sci Pollut Res Int 22: 14546–14559. 10.1007/s11356-015-4202-7.25854201
Kuczmarski, RJ; Ogden, CL; Grummer-Strawn, LM; Flegal, KM; Guo, SS; Wei, R; Mei, Z; Curtin, LR; Roche, AF; Johnson, CL. (2000). CDC growth charts: United States. Hyattsville, MD: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Health Statistics. https://www.cdc.gov/nchs/data/ad/ad314.pdf.
Lau, C. (2015). Perfluorinated compounds: An overview. In JC DeWitt (Ed.), Toxicological effects of perfluoroalkyl and polyfluoroalkyl substances (pp. 1–21). New York: Springer. 10.1007/978-3-319-15518-0_1.
Lau, C; Butenhoff, JL; Rogers, JM. (2004). The developmental toxicity of perfluoroalkyl acids and their derivatives [Review]. Toxicol Appl Pharmacol 198: 231–241. 10.1016/j.taap.2003.11.031.15236955
Lau, C; Thibodeaux, JR; Hanson, RG; Narotsky, MG; Rogers, JM; Lindstrom, AB; Strynar, MJ. (2006). Effects of perfluorooctanoic acid exposure during pregnancy in the mouse. Toxicol Sci 90: 510–518. 10.1093/toxsci/kfj105.16415327
Lau, C; Thibodeaux, JR; Hanson, RG; Rogers, JM; Grey, BE; Stanton, ME; Butenhoff, JL; Stevenson, LA. (2003). Exposure to perfluorooctane sulfonate during pregnancy in rat and mouse. II: postnatal evaluation. Toxicol Sci 74: 382–392. 10.1093/toxsci/kfg122.12773772
Lavado-Autric, R; Auso, E; Garcia-Velasco, JV; del Carmen Arufe, M; Escobar del Rey, F; Berbel, P; Morreale de Escobar, G. (2003). Early maternal hypothyroxinemia alters histogenesis and cerebral cortex cytoarchitecture of the progeny. J Clin Invest 111: 1073–1082. 10.1172/JCI16262.12671057
Levie, D; Korevaar, TIM; Bath, SC; Dalmau-Bueno, A; Murcia, M; Espada, M; Dineva, M; Ibarluzea, JM; Sunyer, J; Tiemeier, H; Rebagliato, M; Rayman, MP; Peeters, RP; Guxens, M. (2018). Thyroid Function in Early Pregnancy, Child IQ, and Autistic Traits: A Meta-Analysis of Individual Participant Data. J Clin Endocrinol Metab 103: 2967–2979. 10.1210/jc.2018-00224.29757392
Li, J; Cai, D; Chu, C; Li, QQ; Zhou, Y; Hu, LW; Yang, BY; Dong, GH; Zeng, XW; Chen, D. (2020). Transplacental Transfer of Per- and Polyfluoroalkyl Substances (PFASs): Differences between Preterm and Full-Term Deliveries and Associations with Placental Transporter mRNA Expression. Environ Sci Technol 54: 5062–5070. 10.1021/acs.est.0c00829.32208722
Li, M; Zeng, XW; Qian, ZM; Vaughn, MG; Sauvé, S; Paul, G; Lin, S; Lu, L; Hu, LW; Yang, BY; Zhou, Y; Qin, XD; Xu, SL; Bao, WW; Zhang, YZ; Yuan, P; Wang, J; Zhang, C; Tian, YP; Nian, M; Xiao, X; Fu, C; Dong, GH. (2017a). Isomers of perfluorooctanesulfonate (PFOS) in cord serum and birth outcomes in China: Guangzhou Birth Cohort Study. Environ Int 102: 1–8. 10.1016/j.envint.2017.03.006.28297681
Li, Y; Cheng, Y; Xie, Z; Zeng, F. (2017b). Perfluorinated alkyl substances in serum of the southern Chinese general population and potential impact on thyroid hormones. Sci Rep 7: 43380. 10.1038/srep43380.28240244
Liu, X; Guo, Z; Krebs, KA; Pope, RH; Roache, NF. (2014). Concentrations and trends of perfluorinated chemicals in potential indoor sources from 2007 through 2011 in the US. Chemosphere 98: 51–57. 10.1016/j.chemosphere.2013.10.001.24268172
Ljubojevic, M; Balen, D; Breljak, D; Kusan, M; Anzai, N; Bahn, A; Burckhardt, G; Sabolic, I. (2007). Renal expression of organic anion transporter OAT2 in rats and mice is regulated by sex hormones. Am J Physiol Renal Physiol 292: F361–F372. 10.1152/ajprenal.00207.2006.16885152
Ljubojevic, M; Herak-Kramberger, CM; Hagos, Y; Bahn, A; Endou, H; Burckhardt, G; Sabolic, I. (2004). Rat renal cortical OAT1 and OAT3 exhibit gender differences determined by both androgen stimulation and estrogen inhibition. Am J Physiol Renal Physiol 287: F124–F138. 10.1152/ajprenal.00029.2004.15010355
Loccisano, AE; Campbell, JL, Jr; Andersen, ME; Clewell, HJ, III. (2011). Evaluation and prediction of pharmacokinetics of PFOA and PFOS in the monkey and human using a PBPK model. Regul Toxicol Pharmacol 59: 157–175. 10.1016/j.yrtph.2010.12.004.21168463
López-Espíndola, D; García-Aldea, Á; Gómez de la Riva, I; Rodríguez-García, AM; Salvatore, D; Visser, TJ; Bernal, J; Guadaño-Ferraz, A. (2019). Thyroid hormone availability in the human fetal brain: novel entry pathways and role of radial glia. Brain Struct Funct 224: 2103–2119. 10.1007/s00429-019-01896-8.31165302
Lorenzo, M; Farré, M; Blasco, C; Onghena, M; Picó, Y; Barceló, D. (2016). Perfluoroalkyl substances in Breast milk, infant formula and baby food from Valencian Community (Spain). Environ Nanotechnol Monit Manag 6: 108–115. 10.1016/j.enmm.2016.09.001.
Luz, AL; Anderson, JK; Goodrum, P; Durda, J. (2019). Perfluorohexanoic acid toxicity, part I: Development of a chronic human health toxicity value for use in risk assessment. Regul Toxicol Pharmacol 103: 41–55. 10.1016/j.yrtph.2019.01.019.30639337
Malhi, H; Gores, GJ; Lemasters, JJ. (2006). Apoptosis and necrosis in the liver: A tale of two deaths? [Review]. Hepatology 43: S31–S44. 10.1002/hep.21062.16447272
Matsuzaki, H; Katsumata, S; Masuyama, R; Uehara, M; Nakamura, K; Suzuki, K. (2002). Sex differences in kidney mineral concentrations and urinary albumin excretion in rats given high-phosphorus feed. Biosci Biotechnol Biochem 66: 1737–1739. 10.1271/bbb.66.1737.12353637
MDH (Minnesota Department of Health). (2017). PFBA and Drinking Water. https://www.health.state.mn.us/communities/environment/risk/docs/guidance/gw/pfbainfo.pdf.
MDH (Minnesota Department of Health). (2018). Health based guidance for water: Perfluorooctanoic acid toxicological summary. Health Risk Assessment Unit, Environmental Health Division, Minnesota Department of Health. https://www.health.state.mn.us/communities/environment/risk/docs/guidance/gw/pfoa.pdf.
MDH (Minnesota Department of Health). (2019). Health Based Guidance for Water: Toxicological Summary for: Perfluorohexane sulfonate (PFHxS). https://www.health.state.mn.us/communities/environment/risk/docs/guidance/gw/pfhxs.pdf.
MDH (Minnesota Department of Health). (2020). Health Based Guidance for Water: Toxicological Summary for: Perfluorooctane Sulfonate (PFOS). https://www.health.state.mn.us/communities/environment/risk/docs/guidance/gw/pfos.pdf.
Mellor, CL; Steinmetz, FP; Cronin, MT. (2016). The identification of nuclear receptors associated with hepatic steatosis to develop and extend adverse outcome pathways [Review]. Crit Rev Toxicol 46: 138–152. 10.3109/10408444.2015.1089471.26451809
Miller, MD; Crofton, KM; Rice, DC; Zoeller, RT. (2009). Thyroid-disrupting chemicals: interpreting upstream biomarkers of adverse outcomes [Review]. Environ Health Perspect 117: 1033–1041. 10.1289/ehp.0800247.19654909
Mirabella, G; Feig, D; Astzalos, E; Perlman, K; Rovet, JF. (2000). The effect of abnormal intrauterine thyroid hormone economies on infant cognitive abilities. J Pediatr Endocrinol Metab 13: 191–194.10711665
Mochizuki, K; Yagi, E; Sakaguchi, N; Mochizuki, H; Takabe, S; Kuranuki, S; Suzuki, T; Shimada, M; Goda, T. (2007). The critical period for thyroid hormone responsiveness through thyroid hormone receptor isoform alpha in the postnatal small intestine. Biochim Biophys Acta 1770: 609–616. 10.1016/j.bbagen.2006.12.011.17292555
Morgan, RL; Thayer, KA; Bero, L; Bruce, N; Falck-Ytter, Y; Ghersi, D; Guyatt, G; Hooijmans, C; Langendam, M; Mandrioli, D; Mustafa, RA; Rehfuess, EA; Rooney, AA; Shea, B; Silbergeld, EK; Sutton, P; Wolfe, MS; Woodruff, TJ; Verbeek, JH; Holloway, AC; Santesso, N; Schünemann, HJ. (2016). GRADE: Assessing the quality of evidence in environmental and occupational health. Environ Int 92–93: 611–616. 10.1016/j.envint.2016.01.004.
Morreale de Escobar, G; Obregon, MJ; Escobar del Rey, F. (2004). Role of thyroid hormone during early brain development [Review]. Eur J Endocrinol 151 Suppl 3: U25–U37. 10.1530/eje.0.151u025.15554884
Mullur, R; Liu, YY; Brent, GA. (2014). Thyroid hormone regulation of metabolism [Review]. Physiol Rev 94: 355–382. 10.1152/physrev.00030.2013.24692351
Nian, M; Li, QQ; Bloom, M; Qian, ZM; Syberg, KM; Vaughn, MG; Wang, SQ; Wei, Q; Zeeshan, M; Gurram, N; Chu, C; Wang, J; Tian, YP; Hu, LW; Liu, KK; Yang, BY; Liu, RQ; Feng, D; Zeng, XW; Dong, GH. (2019a). Liver function biomarkers disorder is associated with exposure to perfluoroalkyl acids in adults: Isomers of C8 Health Project in China. Environ Res 172: 81–88. 10.1016/j.envres.2019.02.013.30776734
Nian, M; Li, QQ; Bloom, M; Qian, ZM; Syberg, KM; Vaughn, MG; Wang, SQ; Wei, Q; Zeeshan, M; Gurram, N; Chu, C; Wang, J; Tian, YP; Hu, LW; Liu, KK; Yang, BY; Liu, RQ; Feng, D; Zeng, XW; Dong, GH. (2019b). Liver function biomarkers disorder is associated with exposure to perfluoroalkyl acids in adults: Isomers of C8 Health Project in China: Supplemental material [Supplemental Data]. Environ Res 172.
Nilsson, H; Kärrman, A; Westberg, H; Rotander, A; van Bavel, B; Lindström, G. (2010). A time trend study of significantly elevated perfluorocarboxylate levels in humans after using fluorinated ski wax. Environ Sci Technol 44: 2150–2155. 10.1021/es9034733.20158198
NJDWQI (New Jersey Drinking Water Quality Institute). (2017). Public review draft: Health-based maximum contaminant level support document: Perfluorooctane sulfonate (PFOS) (CAS #: 1763-23-1; Chemical Formula: C8HF17O3S). NJDWQI Health Effects Subcommittee. https://cswab.org/wp-content/uploads/2018/09/New-Jersey-Scientific-Documentation-Supporting-PFOS-13-ppt.pdf.
NLM (National Library of Medicine). (2013). HSDB: Perfluoro-n-nonanoic acid. Available online at https://pubchem.ncbi.nlm.nih.gov/source/hsdb/8040
NLM (National Library of Medicine). (2016). TOXNET Toxicology Data Network, Hazardous Substances Database (HSDB): Perfluorohexanoic acid. Available online at https://toxnet.nlm.nih.gov/cgi-bin/sis/search/a?dbs+hsdb:@term+@DOCNO+8299
NLM (National Library of Medicine). (2017). HSDB: Perfluorohexanesulfonic acid. Available online at https://pubchem.ncbi.nlm.nih.gov/source/hsdb/8274
NTP (National Toxicology Program). (2018). 28-day evaluation of the toxicity (C20613) of perfluorohexanoic acid (PFHxA) (307-24-4) on Harlan Sprague-Dawley rats exposed via gavage. Available online at https://tools.niehs.nih.gov/cebs3/views/?action=main.dataReview&bin_id=3879
NTP (National Toxicology Program). (2019). NTP technical report on the toxicity studies of perfluoroalkyl carboxylates (perfluorohexanoic acid, perfluorooctanoic acid, perfluorononanoic acid, and perfluorodecanoic acid) administered by gavage to Sprague Dawley (Hsd:Sprague Dawley SD) rats [NTP]. (Toxicity Report 97). Research Triangle Park, NC. https://ntp.niehs.nih.gov/ntp/htdocs/st_rpts/tox097_508.pdf.
O’Shaughnessy, KL; Kosian, PA; Ford, JL; Oshiro, WM; Degitz, SJ; Gilbert, ME. (2018). Developmental Thyroid Hormone Insufficiency Induces a Cortical Brain Malformation and Learning Impairments: A Cross-Fostering Study. Toxicol Sci 163: 101–115. 10.1093/toxsci/kfy016.29385626
Obregon, MJ; Calvo, RM; Del Rey, FE; de Escobar, GM. (2007). Ontogenesis of thyroid function and interactions with maternal function [Review]. Endocr Dev 10: 86–98. 10.1159/000106821.17684391
OECD (Organisation for Economic Co-operation and Development). (2010). Test No. 417: Toxicokinetics. In OECD guidelines for the testing of chemicals, section 4. Paris, France: OECD Publishing. 10.1787/9789264070882-en.
OECD (Organisation for Economic Co-operation and Development). (2018). Toward a new comprehensive global database of per- and polyfluoroalkyl substances (PFASs): Summary report on updating the OECD 2007 list of per- and polyfluoroalkyl substances (PFASs). (ENV/JM/MONO(2018)7). Paris, France. http://www.oecd.org/chemicalsafety/portal-perfluorinated-chemicals/.
Paaby, P. (1960). Changes in serum proteins during pregnancy. J Obstet Gynaecol Br Emp 67: 43–55. 10.1111/j.1471-0528.1960.tb06949.x.14429618
Patel, J; Landers, K; Li, H; Mortimer, RH; Richard, K. (2011). Thyroid hormones and fetal neurological development [Review]. J Endocrinol 209: 1–8. 10.1530/JOE-10-0444.21212091
Pérez, F; Nadal, M; Navarro-Ortega, A; Fàbrega, F; Domingo, JL; Barceló, D; Farré, M. (2013). Accumulation of perfluoroalkyl substances in human tissues. Environ Int 59: 354–362. 10.1016/j.envint.2013.06.004.23892228
Permadi, H; Lundgren, B; Andersson, K; Depierre, JW. (1992). Effects of perfluoro fatty acids on xenobiotic-metabolizing enzymes, enzymes which detoxify reactive forms of oxygen and lipid peroxidation in mouse liver. Biochem Pharmacol 44: 1183–1191. 10.1016/0006-2952(92)90383-T.1417940
Permadi, H; Lundgren, B; Andersson, K; Sundberg, C; Depierre, JW. (1993). Effects of perfluoro fatty acids on peroxisome proliferation and mitochondrial size in mouse liver: dose and time factors and effect of chain length. Xenobiotica 23: 761–770. 10.3109/00498259309166782.8237058
Post, GB; Louis, JB; Lippincott, RL; Procopio, NA. (2013). Occurrence of perfluorinated compounds in raw water from New Jersey public drinking water systems. Environ Sci Technol 47: 13266–13275. 10.1021/es402884x.24187954
Prevedouros, K; Cousins, IT; Buck, RC; Korzeniowski, SH. (2006). Sources, fate and transport of perfluorocarboxylates [Review]. Environ Sci Technol 40: 32–44. 10.1021/es0512475.16433330
Prevot, V. (2014). Chapter 30 - puberty in mice and rats. In Knobil and Neill’s Physiology of Reproduction (Fourth Edition) (4 ed.). Lille, France: Laboratory of Development and Plasticity of the Neuroendocrine Brain, Jean-Pierre Aubert Research Center, School of Medicine, University of Lille. 10.1016/B978-0-12-397175-3.00030-2.
Puig-Domingo, M; Vila, L. (2013). The implications of iodine and its supplementation during pregnancy in fetal brain development [Review]. Curr Clin Pharmacol 8: 97–109.23062035
Rao, JNK; Scott, AJ. (1992). A simple method for the analysis of clustered binary data. Biometrics 48: 577–585. 10.2307/2532311.1637980
Robinson, PJ; Rapoport, SI. (1986). Kinetics of protein binding determine rates of uptake of drugs by brain. Am J Physiol Regul Integr Comp Physiol 251: R1212–R1220. 10.1152/ajpregu.1986.251.6.R1212.
Román, GC; Ghassabian, A; Bongers-Schokking, JJ; Jaddoe, VW; Hofman, A; de Rijke, YB; Verhulst, FC; Tiemeier, H. (2013). Association of gestational maternal hypothyroxinemia and increased autism risk : Supplementary materials. Ann Neurol 74: 733–742.23943579
Rosen, MB; Das, KP; Rooney, J; Abbott, B; Lau, C; Corton, JC. (2017). PPARα-independent transcriptional targets of perfluoroalkyl acids revealed by transcript profiling. Toxicology 387: 95–107. 10.1016/j.tox.2017.05.013.28558994
Rosen, MB; Das, KP; Wood, CR; Wolf, CJ; Abbott, BD; Lau, C. (2013). Evaluation of perfluoroalkyl acid activity using primary mouse and human hepatocytes. Toxicology 308: 129–137. 10.1016/j.tox.2013.03.011.23567314
Rosenmai, AK; Ahrens, L; le Godec, T; Lundqvist, J; Oskarsson, A. (2018). Relationship between peroxisome proliferator-activated receptor alpha activity and cellular concentration of 14 perfluoroalkyl substances in HepG2 cells. J Appl Toxicol 38: 219–226. 10.1002/jat.3515.28857218
Ruan, T; Sulecki, LM; Wolstenholme, BW; Jiang, G; Wang, N; Buck, RC. (2014). 6:2 Fluorotelomer iodide in vitro metabolism by rat liver microsomes: comparison with [1,2-(14)C] 6:2 fluorotelomer alcohol. Chemosphere 112: 34–41. 10.1016/j.chemosphere.2014.02.068.25048885
Russell, JJ; Heaton, JC; Underwood, T; Boughtflower, R; Mccalley, DV. (2015a). Performance of charged aerosol detection with hydrophilic interaction chromatography. J Chromatogr A 1405: 72–84. 10.1016/j.chroma.2015.05.050.26091786
Russell, MH; Himmelstein, MW; Buck, RC. (2015b). Inhalation and oral toxicokinetics of 6:2 FTOH and its metabolites in mammals. Chemosphere 120: 328–335. 10.1016/j.chemosphere.2014.07.092.25180935
Schünemann, H; Hill, S; Guyatt, G; Akl, EA; Ahmed, F. (2011). The GRADE approach and Bradford Hill’s criteria for causation. J Epidemiol Community Health 65: 392–395. 10.1136/jech.2010.119933.20947872
Sferruzzi-Perri, AN; Vaughan, OR; Forhead, AJ; Fowden, AL. (2013). Hormonal and nutritional drivers of intrauterine growth [Review]. Curr Opin Clin Nutr Metab Care 16: 298–309. 10.1097/MCO.0b013e32835e3643.23340010
Sharlin, DS; Gilbert, ME; Taylor, MA; Ferguson, DC; Zoeller, RT. (2010). The nature of the compensatory response to low thyroid hormone in the developing brain. J Neuroendocrinol 22: 153–165. 10.1111/j.1365-2826.2009.01947.x.20041985
Song, X; Tang, S; Zhu, H; Chen, Z; Zang, Z; Zhang, Y; Niu, X; Wang, X; Yin, H; Zeng, F; He, C. (2018). Biomonitoring PFAAs in blood and semen samples: Investigation of a potential link between PFAAs exposure and semen mobility in China. Environ Int 113: 50–54. 10.1016/j.envint.2018.01.010.29421407
Stagnaro-Green, A; Rovet, J. (2016). Pregnancy: Maternal thyroid function in pregnancy - A tale of two tails [Comment]. Nat Rev Endocrinol 12: 10–11. 10.1038/nrendo.2015.212.26635112
Stahl, LL; Snyder, BD; Olsen, AR; Kincaid, TM; Wathen, JB; Mccarty, HB. (2014). Perfluorinated compounds in fish from U.S. urban rivers and the Great Lakes. Sci Total Environ 499: 185–195. 10.1016/j.scitotenv.2014.07.126.25190044
Stenzel, D; Huttner, WB. (2013). Role of maternal thyroid hormones in the developing neocortex and during human evolution. Frontiers in Neuroanatomy 7: 9. 10.3389/fnana.2013.00019.23675325
Sun, M; Arevalo, E; Strynar, M; Lindstrom, A; Richardson, M; Kearns, B; Pickett, A; Smith, C; Knappe, DRU. (2016). Legacy and emerging perfluoroalkyl substances are important drinking water contaminants in the Cape Fear River Watershed of North Carolina. Environ Sci Technol Lett 3: 415–419. 10.1021/acs.estlett.6b00398.
Sundström, M; Bogdanska, J; Pham, HV; Athanasios, V; Nobel, S; Mcalees, A; Eriksson, J; Depierre, JW; Bergman, Å. (2012). Radiosynthesis of perfluorooctanesulfonate (PFOS) and perfluorobutanesulfonate (PFBS), including solubility, partition and adhesion studies. Chemosphere 87: 865–871. 10.1016/j.chemosphere.2012.01.027.22336737
U.S. EPA (U.S. Environmental Protection Agency). (1991). Guidelines for developmental toxicity risk assessment. Fed Reg 56: 63798–63826.
U.S. EPA (U.S. Environmental Protection Agency). (1994). Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry [EPA Report]. (EPA600890066F). Research Triangle Park, NC. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=71993&CFID=51174829&CFTOKEN=25006317.
U.S. EPA (U.S. Environmental Protection Agency). (1996). Guidelines for reproductive toxicity risk assessment. Fed Reg 61: 56274–56322.
U.S. EPA (U.S. Environmental Protection Agency). (1998a). Assessment of thyroid follicular cell tumors [EPA Report] (pp. 1–51). (EPA/630/R-97/002). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/sites/production/files/2014-11/documents/thyroid.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (1998b). Guidelines for neurotoxicity risk assessment [EPA Report] (pp. 1–89). (ISSN 0097-6326 EISSN 2167-2520 EPA/630/R-95/001F). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. http://www.epa.gov/risk/guidelines-neurotoxicity-risk-assessment.
U.S. EPA (U.S. Environmental Protection Agency). (2002). A review of the reference dose and reference concentration processes. (EPA630P02002F). Washington, DC. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2005). Guidelines for carcinogen risk assessment [EPA Report]. (EPA630P03001F). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3-25-05.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2011). Recommended use of body weight 3/4 as the default method in derivation of the oral reference dose. (EPA100R110001). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/recommended-use-of-bw34.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2012). Benchmark dose technical guidance [EPA Report]. (EPA100R12001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/benchmark-dose-technical-guidance.
U.S. EPA (U.S. Environmental Protection Agency). (2013). U.S. Environmental Protection Agency endocrine disruptor screening program SAP review of EDSP tier 1 screening: Assay and battery performance.
U.S. EPA (U.S. Environmental Protection Agency). (2016a). Health effects support document for perfluorooctane sulfonate (PFOS) [EPA Report]. (EPA 822-R-16-002). Washington, DC: U.S. Environmental Protection Agency, Office of Water, Health and Ecological Criteria Division. https://www.epa.gov/sites/production/files/2016-05/documents/pfos_hesd_final_508.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2016b). Health effects support document for perfluorooctanoic acid (PFOA) [EPA Report]. (EPA 822-R-16-003). Washington, DC: U.S. Environmental Protection Agency, Office of Water, Health and Ecological Criteria Division. https://www.epa.gov/sites/production/files/2016-05/documents/pfoa_hesd_final-plain.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2018a). Chemistry Dashboard. Washington, DC. Retrieved from https://comptox.epa.gov/dashboard
U.S. EPA (U.S. Environmental Protection Agency). (2018b). Human health toxicity values for perfluorobutane sulfonic acid (CASRN 375-73-5) and related compound potassium perfluorobutane sulfonate (CASRN 29420-49-3) (public comment draft). (EPA-823-R-18-307). Washington, DC.
U.S. EPA (U.S. Environmental Protection Agency). (2019a). ChemView [Database]. Retrieved from https://chemview.epa.gov/chemview
U.S. EPA (U.S. Environmental Protection Agency). (2019b). EPA Actions to Address PFAS. Available online at https://www.epa.gov/pfas/epa-actions-address-pfas
U.S. EPA (U.S. Environmental Protection Agency). (2020). Umbrella quality assurance project plan (QAPP) for dosimetry and mechanism-based models. (EPA QAPP ID Number: L-CPAD-0032188-QP-1-2). Research Triangle Park, NC.
U.S. EPA (U.S. Environmental Protection Agency). (2021a). Human health toxicity values for hexafluoropropylene oxide (HFPO) dimer acid and its ammonium salt (CASRN 13252-13-6 and CASRN 62037-80-3). Also known as “GenX chemicals.” Final report [EPA Report]. (EPA-822R-21-010). Washington, DC: U.S. Environmental Protection Agency, Office of Water.
U.S. EPA (U.S. Environmental Protection Agency). (2021b). Human health toxicity values for perfluorobutane sulfonic acid (CASRN 375-73-5) and related compound potassium perfluorobutane sulfonate (CASRN 29420-49-3) [EPA Report]. (EPA/600/R-20/345F). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=350888.
Van Camp, I; Ritskes-Hoitinga, J; Lemmens, AG; Beynen, AC. (1990). Diet-induced nephrocalcinosis and urinary excretion of albumin in female rats. Lab Anim 24: 137–141. 10.1258/002367790780890086.2142229
Van Cruchten, S; Van Den Broeck, W. (2002). Morphological and biochemical aspects of apoptosis, oncosis and necrosis [Review]. Anat Histol Embryol 31: 214–223. 10.1046/j.1439-0264.2002.00398.x.12196263
van Otterdijk, FM. (2007a). Repeated dose 28-day oral toxicity study with MTDID-8391 by daily gavage in the rat, followed by a 21-day recovery period. (Study Number 06-226). Maplewood, MN: 3M.
van Otterdijk, FM. (2007b). Repeated dose 90-day oral toxicity study with MTDID 8391 by daily gavage in the rat followed by a 3-week recovery period. (Study Number 06-398). Maplewood, MN: 3M.
Venkatesan, AK; Halden, RU. (2014). Loss and in situ production of perfluoroalkyl chemicals in outdoor biosolids-soil mesocosms. Environ Res 132: 321–327. 10.1016/j.envres.2014.04.024.24834828
Vulsma, T; Gons, MH; de Vijlder, JJ. (1989). Maternal-fetal transfer of thyroxine in congenital hypothyroidism due to a total organification defect or thyroid agenesis. N Engl J Med 321: 13–16. 10.1056/NEJM198907063210103.2733742
Wahlang, B; Beier, JI; Clair, HB; Bellis-Jones, HJ; Falkner, K; Mcclain, CJ; Cave, MC. (2013). Toxicant-associated steatohepatitis [Review]. Toxicol Pathol 41: 343–360. 10.1177/0192623312468517.23262638
Wang, J; Zeng, XW; Bloom, MS; Qian, Z; Hinyard, LJ; Belue, R; Lin, S; Wang, SQ; Tian, YP; Yang, M; Chu, C; Gurram, N; Hu, LW; Liu, KK; Yang, BY; Feng, D; Liu, RQ; Dong, GH. (2019). Renal function and isomers of perfluorooctanoate (PFOA) and perfluorooctanesulfonate (PFOS): Isomers of C8 Health Project in China. Chemosphere 218: 1042–1049. 10.1016/j.chemosphere.2018.11.191.30609483
Wang, Z; Cousins, IT; Scheringer, M; Buck, RC; Hungerbühler, K. (2014). Global emission inventories for C4-C14 perfluoroalkyl carboxylic acid (PFCA) homologues from 1951 to 2030, Part I: production and emissions from quantifiable sources [Review]. Environ Int 70: 62–75. 10.1016/j.envint.2014.04.013.24932785
Watkins, DJ; Josson, J; Elston, B; Bartell, SM; Shin, HM; Vieira, VM; Savitz, DA; Fletcher, T; Wellenius, GA. (2013). Exposure to perfluoroalkyl acids and markers of kidney function among children and adolescents living near a chemical plant. Environ Health Perspect 121: 625–630. 10.1289/ehp.1205838.23482063
Weatherly, LM; Shane, HL; Lukomska, E; Baur, R; Anderson, SE. (2021). Systemic toxicity induced by topical application of heptafluorobutyric acid (PFBA) in a murine model. Food Chem Toxicol 156: 112528. 10.1016/j.fct.2021.112528.34474067
Weaver, YM; Ehresman, DJ; Butenhoff, JL; Hagenbuch, B. (2010). Roles of rat renal organic anion transporters in transporting perfluorinated carboxylates with different chain lengths. Toxicol Sci 113: 305–314. 10.1093/toxsci/kfp275.19915082
Wexler, JA; Sharretts, J. (2007). Thyroid and bone [Review]. Endocrinol Metab Clin North Am 36: 673–705, vi. 10.1016/j.ecl.2007.04.005.17673124
Wiesel, TN. (1982). The postnatal development of the visual cortex and the influence of environment [Review]. Biosci Rep 2: 351–377. 10.1007/bf01119299.7049262
Williams, GM; Iatropoulos, MJ. (2002). Alteration of liver cell function and proliferation: Differentiation between adaptation and toxicity [Review]. Toxicol Pathol 30: 41–53. 10.1080/01926230252824699.11890475
Williams, GR. (2008). Neurodevelopmental and neurophysiological actions of thyroid hormone [Review]. J Neuroendocrinol 20: 784–794. 10.1111/j.1365-2826.2008.01733.x.18601701
Wolf, CJ; Schmid, JE; Lau, C; Abbott, BD. (2012). Activation of mouse and human peroxisome proliferator-activated receptor-alpha (PPARα) by perfluoroalkyl acids (PFAAs): further investigation of C4-C12 compounds. Reprod Toxicol 33: 546–551. 10.1016/j.reprotox.2011.09.009.22107727
Wolf, CJ; Takacs, ML; Schmid, JE; Lau, C; Abbott, BD. (2008). Activation of mouse and human peroxisome proliferator-activated receptor alpha by perfluoroalkyl acids of different functional groups and chain lengths. Toxicol Sci 106: 162–171. 10.1093/toxsci/kfn166.18713766
Yang, CH; Glover, KP; Han, X. (2009). Organic anion transporting polypeptide (Oatp) 1a1-mediated perfluorooctanoate transport and evidence for a renal reabsorption mechanism of Oatp1a1 in renal elimination of perfluorocarboxylates in rats. Toxicol Lett 190: 163–171. 10.1016/j.toxlet.2009.07.011.19616083
Zeng, XW; Li, QQ; Chu, C; Ye, WL; Yu, S; Ma, H; Zeng, XY; Zhou, Y; Yu, HY; Hu, LW; Yang, BY; Dong, GH. (2020). Alternatives of perfluoroalkyl acids and hepatitis B virus surface antibody in adults: Isomers of C8 Health Project in China. Environ Pollut 259: 113857. 10.1016/j.envpol.2019.113857.31918137
Zhang, YM; Dong, XY; Fan, LJ; Zhang, ZL; Wang, Q; Jiang, N; Yang, XS. (2017). Poly- and perfluorinated compounds activate human pregnane X receptor. Toxicology 380: 23–29. 10.1016/j.tox.2017.01.012.28115241
Zhao, H; Qu, B; Guan, Y; Jiang, J; Chen, X. (2016). Influence of salinity and temperature on uptake of perfluorinated carboxylic acids (PFCAs) by hydroponically grown wheat (Triticum aestivum L.). SpringerPlus 5: 541. 10.1186/s40064-016-2016-9.27186505
Zoeller, RT; Crofton, KM. (2000). Thyroid hormone action in fetal brain development and potential for disruption by environmental chemicals [Review]. Neurotoxicology 21: 935–945.11233763
Zoeller, RT; Dowling, ALS; Vas, AA. (2000). Developmental exposure to polychlorinated biphenyls exerts thyroid hormone-like effects on the expression of RC3/neurogranin and myelin basic protein messenger ribonucleic acids in the developing rat brain. Endocrinology 141: 181–189. 10.1210/endo.141.1.7273.10614638
Zoeller, RT; Rovet, J. (2004). Timing of thyroid hormone action in the developing brain: Clinical observations and experimental findings [Review]. J Neuroendocrinol 16: 809–818. 10.1111/j.1365-2826.2004.01243.x.15500540
Zoeller, RT; Tan, SW; Tyl, RW. (2007). General background on the hypothalamic-pituitary-thyroid (HPT) axis [Review]. Crit Rev Toxicol 37: 11–53. 10.1080/10408440601123446.17364704