# AUTHORS|CONTRIBUTORS|REVIEWERS

Assessment Managers (Lead Authors)
J. Allen Davis (https://orcid.org/0000-0002-3238-3849), M.S.P.H.; Michele M. Taylor (https://orcid.org/0000-0001-5049-0499), Ph.D. | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Authors
Andrew Kraft (https://orcid.org/0000-0003-3630-6741), Ph.D.; Jason C. Lambert (https://orcid.org/0000-0003-0549-4241), Ph.D.; Elizabeth Radke (https://orcid.org/0000-0002-2504-2405), Ph.D.; Paul Schlosser (https://orcid.org/0000-0002-9699-9108), Ph.D. | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Contributors
Michelle Angrish (https://orcid.org/0000-0002-4956-4806), Ph.D.; Xabier Arzuaga (https://orcid.org/0000-0002-7978-5431), Ph.D.; Johanna Congleton, Ph.D.; Ingrid Druwe (https://orcid.org/0000-0002-0591-0295), Ph.D.; Mary Gilbert, Ph.D.; Christopher Lau, Ph.D.; Pamela Noyes (https://orcid.org/0000-0003-1654-4056), Ph.D.; Katherine O’Shaughnessy, Ph.D.; Elizabeth Oesterling Owens, Ph.D.; Tammy Stoker, Ph.D.; Andre Weaver (https://orcid.org/0000-0001-8580-6350), Ph.D.; Amina Wilkins (https://orcid.org/0000-0001-9292-833X), M.P.H.; Michael Wright (https://orcid.org/0000-0001-6813-9760), Sc.D.; Jay Zhao (https://orcid.org/0000-0001-7600-8840), Ph.D. | U.S. EPA/Office of Research and Development/Center for Public Health and Environmental Assessment
Chris Corton, Ph.D. | U.S. EPA/Office of Research and Development/Center for Computational Toxicology and Exposure
April Luke, M.S. | U.S. EPA/Office of Land and Emergency Management
Kelly Garcia, B.S.; Andrew Greenhalgh, B.S.; Carolyn Gigot, B.A. | Oak Ridge Associated Universities (ORAU) Contractor
Production Team
Maureen Johnson; Ryan Jones; Dahnish Shams; Jessica Soto-Hernandez; Vicki Soto; Samuel Thacker; Garland Waleko | U.S. EPA; Office of Research and Development; Center for Public Health and Environmental Assessment
Rebecca Schaefer | Oak Ridge Associated Universities (ORAU) Contractor
Executive Direction
Wayne Cascio | CPHEA Center Director
V. Kay Holt | CPHEA Deputy Center Director
Samantha Jones | CPHEA Associate Director
Kristina Thayer | CPAD Division Director
Andrew Kraft | CPAD Associate Division Director, IRIS PFAS Team Lead
Janice Lee | CPHEA/CPAD/Toxic Effects Assessment (RTP) Branch Chief
Barbara Glenn | CPHEA/CPAD (retired)
Viktor Morozov | CPHEA/CPAD/Quantitative Assessment Branch Chief

## Review

### CPAD Executive Review Committee

Kristina Thayer | CPAD Division Director
Paul White | CPHEA/CPAD/Senior Science Advisor
Ravi Subramaniam | CPHEA/CPAD/Toxic Effects Assessment (DC) Branch Chief
Karen Hogan | CPHEA/CPAD/Emeritus
Alan Stern | NJDEP (retired), Contractor

### Agency Reviewers

This assessment was provided for review to scientists in EPA’s program and regional offices. Comments were submitted by:

- Office of the Administrator/Office of Children’s Health Protection
- Office of Air and Radiation/Office of Air Quality Planning and Standards
- Office of Chemical Safety and Pollution Prevention/Office of Pollution Prevention and Toxics
- Office of Children’s Health Protection
- Office of Land and Emergency Management
- Office of Water
- Region 2, New York
- Region 3, Philadelphia
- Region 8, Denver

### Interagency Reviewers

This assessment was provided for review to other federal agencies and the Executive Office of the President (EOP). A summary and EPA’s disposition of major comments from the other federal agencies and EOP is available on the IRIS website. Comments were submitted by:

- The White House
  - Office of Management and Budget
- Department of Defense
- Department of Health and Human Services
  - Agency for Toxic Substances and Disease Registry
  - National Institute for Occupational Safety and Health
  - National Institute of Environmental Health Sciences