# DISCLAIMER

This document has been reviewed by the U.S. Environmental Protection Agency, Office of Research and Development and approved for publication. Any mention of trade names, products, or services does not imply an endorsement by the U.S. government or the U.S. Environmental Protection Agency. EPA does not endorse any commercial products, services, or enterprises.