# 5 DERIVATION OF TOXICITY VALUES

## 5.1 NONCANCER AND CANCER HEALTH EFFECT CATEGORIES CONSIDERED

The available evidence indicates that oral exposure to PFBA is likely to cause adverse thyroid, hepatic, and developmental effects in humans based on multiple high and medium confidence animal toxicity studies (Butenhoff et al., 2012a; Foreman et al., 2009; Das et al., 2008; van Otterdijk, 2007a, b; Permadi et al., 1993; Permadi et al., 1992).

No human or animal toxicity studies are available to inform the potential for PFBA to cause adverse effects via inhalation. Likewise, no human or animal studies are available to inform the potential for oral or inhalation exposure to cause genotoxicity or cancer.

## 5.2 NONCANCER TOXICITY VALUES

The noncancer oral toxicity values (i.e., reference doses) derived in this section are estimates of an exposure for a given duration to the human population (including susceptible subgroups and lifestages) that is likely to be without an appreciable risk of adverse health effects over a lifetime. The RfD derived in Section 5.2.1 corresponds to chronic, lifetime exposure and is the primary focus of this document. In addition, RfDs specific to each organ or system are provided (organ/system-specific RfDs), as these toxicity values might be useful in some contexts (e.g., when assessing the potential cumulative effects of multiple chemical exposures occurring simultaneously). Less-than-lifetime, subchronic toxicity values (including the subchronic RfD and organ/system-specific subchronic RfDs), which are derived in Section 5.2.2, correspond to exposure durations between 30 days and 10% of the life span in humans. These subchronic toxicity values are presented because they might be useful for certain decision purposes (e.g., site-specific risk assessments with less-than-lifetime exposures). Section 5.2.3 discusses that no information exists to inform the potential toxicity of inhaled PFBA.

### 5.2.1 Oral Reference Dose (RfD) Derivation

#### Study Selection

Given the identified hazards relating to thyroid, liver, and developmental effects, two high confidence studies reporting these effects were selected for the purpose of deriving an oral reference dose (RfD). The subchronic Butenhoff et al. (2012a) and developmental Das et al. (2008) studies were selected to support RfD derivation given the ability of these study designs to estimate potential effects of lifetime exposure, as compared to short-term or acute studies. Both studies used rats or mice as the laboratory animal species and used vehicle-exposed controls. Animals were exposed to reagent-grade NH_4_^+^PFB (reported as >98% pure or as a 28.9% solution in distilled water; impurities not reported) via a relevant route (oral administration via gavage) and for a relevant duration (90 days or GD 1−17) of exposure.

Also available in the PFBA database are two short-term (i.e., 28-day) studies that provide information on the hepatic and thyroid effects of PFBA (Butenhoff et al., 2012a; Foreman et al., 2009; van Otterdijk, 2007a). Although these studies were used for qualitative hazard identification purposes (they supported the final evidence integration judgments for these endpoints and thus were critical for identifying these endpoints for dose-response analysis), they ultimately were not considered for use as the basis for the quantitative dose-response analyses. When developing a lifetime reference value, chronic or subchronic studies (and studies of developmental exposure) are generally preferred over short-term or acute studies. Likewise, subchronic and developmental studies are preferred when developing a subchronic RfD. Although short-term studies were not used for the identification of points of departure (PODs), however, they were deemed relevant to decisions regarding the application of uncertainty factors for deriving toxicity values (see “Derivation of Candidate Toxicity Values” below).

In the liver, a pattern of adverse effects has been observed in mice and rats, with PFBA exposure resulting in increased liver weights (absolute and relative) in adult exposed animals Butenhoff et al. (2012a); Das et al. (2008); van Otterdijk (2007b) in conjunction with histopathological lesions [i.e., hepatocellular hypertrophy; Butenhoff et al. (2012a); van Otterdijk (2007b)]. As discussed in Section 3.2.2, the observed effects in the livers of exposed experimental animals are judged relevant to human health as evidenced by the observation of increased liver weights and increased hepatocellular hypertrophy in mice expressing human PPARα and increased vacuolation in humanized-PPARα and PPARα null mice. This strongly suggests a multifaceted mode of action (MOA) for liver effects consisting, in part, of non-PPARα mechanisms operant in humans (noting that activation of human PPARα by PFBA also results in hepatic changes). Further, the observation of vacuolation specifically indicates the observed effects are possible precursors to clearly adverse downstream effects such as steatohepatitis, fibrosis, and cirrhosis. Thus, the observed pattern of liver effects in PFBA-exposed animals are judged to be adverse, relevant to human health, and appropriate to consider for reference value derivation. For the purposes of dose-response modeling, relative liver weights were chosen over absolute liver weights. Although body weights were not affected on average in any PFBA study, relative liver weights are still preferred because this measure of effect accounts for any changes in body weights that occur in individual animals (changes in body and liver weights are associated). For liver hypertrophy, severity information in addition to raw incidence was available. Therefore, both total incidence of lesions and incidence of “slight” severity lesions were considered for dose-response analysis.

A pattern of adverse effects in the thyroid also is observed in exposed rats that consists of decreased free and total T4 levels and increased incidence of thyroid follicular hypertrophy and hyperplasia (Butenhoff et al., 2012a; van Otterdijk, 2007b). Decreased thyroid hormone levels are judged relevant to human health, given the many similarities in the production, regulation, and functioning of thyroid hormones between rodents and humans. For effects on T4, total T4 was chosen for dose-response modeling over free T4, on the basis of lack of data in the control group for free T4 (given insufficient volume for the assay). In addition, rodents are more sensitive to increases in thyroid follicular hypertrophy and hyperplasia, and thus changes in thyroid hormone levels are considered more relevant for deriving human health toxicity values. For this reason, the increases in thyroid hypertrophy/hyperplasia were not considered further for RfD derivation. Note, however, that decreased total T4 was observed at 6 mg/kg-day in rats exposed to PFBA for 28 days, but not in rats exposed for 90 days (where it was observed only at 30 mg/kg-day). This discrepancy can be explained, however, by the difference in serum concentrations following 28- and 90-day exposures. Serum free T4 concentrations were higher in the 6 mg/kg-day dose group following 28-day exposures (24.7 μg/mL) vs. 90-day exposures (6.1 μg/mL). This difference was reversed in the 30 mg/kg-day dose group for the 28-day and 90-day animals, being 38.0 μg/mL vs. 52.2 μg/mL, respectively. Because serum concentrations following chronic exposures likely will resemble those following subchronic exposures (more so than serum concentrations following short-term exposures), the effects on total T4 following subchronic exposure are deemed most appropriate for deriving lifetime and subchronic toxicity values.

Effects on the developing reproductive system included delays in vaginal opening and preputial separation (Das et al., 2008). EPA’s Reproductive Toxicity Guidelines U.S. EPA (1996) states that significant effects in the development of the male and female reproductive systems “either early or delayed, should be considered adverse…” and thus supports considering these endpoints for reference value derivation. Delayed eye opening, also found following PFOA exposure, is identified as a “simple, but reliable” indicator of impaired postnatal development by Das et al. (2008). Further, a delay of eye opening is a form of visual deprivation that prevents ocular visual signals from reaching the brain during a critical period of development (Wiesel, 1982). A time-sensitive critical period in the development of the visual system is when the architecture of the visual cortex is established Espinosa and Stryker (2012), and accordingly, any alterations of the visual system during that time is considered adverse. Evidence in humans further supports the adversity of this endpoint, given that infants born with congenital cataracts that interfere with the processing of visual signals have permanent visual defects if the cataracts are removed after the critical window for visual development (Wiesel, 1982). Therefore, any delay in the development of sight or development of the visual neurological system results in permanent functional decrements and is relevant to human health.

Full litter resorption (FLR), a clear indicator of postimplantation embryo/fetal mortality, was increased twofold and fourfold in pregnant mice exposed to 175 mg/kg-day or 350 mg/kg-day (respectively) during pregnancy. In the uteri of dams without full resorptions, there was additional evidence of fetal resorptions. In addition, in a separate cohort of gestationally exposed dams that were allowed to deliver litters and were killed after their pups were weaned on lactation day 22, there was an indication of decreased pre- and postnatal survival of the offspring (as determined by a comparison of the number of maternal implantation sites to the number of pups delivered), the magnitude of which is considered biologically significant (discussed below). Taken together, the potential coherence of decreased pre- or postnatal survival with other effects on early fetal mortality and developmental maturation (i.e., delays in eye opening and reproductive milestones) supports consideration of all these developmental endpoints for deriving PODs.

Individual animal data were obtained from the study authors, which allowed for a thorough consideration of pre- and postnatal mortality data. When the FLR data were combined with data for prenatal mortality from litters without FLR to provide a more complete assessment of embryo/fetal mortality, the response was statistically significant (p = 0.012) using the Cochran-Armitage trend test with a Rao-Scott adjustment (CA/RS) method (Rao and Scott, 1992). Although the embryo/fetal mortality observed as FLR is presumed to have occurred much earlier in pregnancy than fetal mortality in non-FLR litters and could involve different or overlapping contributing mechanisms, combining these endpoints provides information on pregnancy loss and fetal mortality over the entire gestational period, corresponding to the period of PFBA exposure. This was deemed more appropriate than modeling FLR and non-FLR fetal mortality separately. Combining the data in this way has the added benefit of allowing the data to be modeled with the nested dichotomous models and avoids the lower resolution of modeling the FLR data as dam incidence per dose group.

The individual litter data obtained from the study authors also allowed for consideration of modeling postnatal mortality (i.e., number of neonatal deaths compared to the number of implantation sites). Analysis of the individual litter data revealed a nonmonotonic dose-response for postnatal mortality, with response rates of 0.38%, 1.04%, 2.93%, and 1.2% at 0, 35, 175, and 350 mg/kg-day, respectively, and the CA/RS trend test for the dataset was not statistically significant (p = 0.09). Further, the data for postnatal mortality clearly indicates it is a weaker response compared to prenatal mortality. Given that postnatal mortality was a weaker response than prenatal morality, it failed to achieve statistical significance, and prenatal mortality is more closely aligned with the period of exposure, postnatal mortality was not considered further for POD derivation.

The studies (excluding the short-term studies) and outcomes relevant to the identified hazards were selected and advanced for POD derivation as presented in Table 5-1. These selected datasets were evaluated for toxicity value derivation as described below and in Appendix D.

Table 5-1 Endpoints considered for dose-response modeling and derivation of points of departure

Endpoint | Exposure duration | Species, sex | POD derivation^a^ | Reference^b^
Liver
Increased relative liver weight | Subchronic | S-D rat, male | Yes | Butenhoff et al. (2012a)
Increased relative liver weight | Gestational | CD-1 mouse, female | Yes | Butenhoff et al. (2012a)
Increased absolute liver weight | Subchronic | S-D rat, male | No | Butenhoff et al. (2012a)
Increased absolute liver weight | Gestational | CD-1 mouse, female | No | Butenhoff et al. (2012a)
Increased liver hypertrophy | Subchronic | S-D rat, male | Yes | Butenhoff et al. (2012a)
Thyroid
Decreased total T4 | Subchronic | S-D rat, male | Yes | Butenhoff et al. (2012a)
Decreased free T4 | Subchronic | S-D rat, male | No | Butenhoff et al. (2012a)
Increased thyroid follicular hypertrophy | Subchronic | S-D rat, male | No | Butenhoff et al. (2012a)
Developmental
Embryo/fetal mortality | Gestational | CD-1 mouse, male and female | Yes | Das et al. (2008)
Postnatal mortality | Gestational | CD-1 mouse, male and female | No | Das et al. (2008)
Delayed eye opening | Gestational | CD-1 mouse, male and female | Yes | Das et al. (2008)
Delayed vaginal opening | Gestational | CD-1 mouse, female | Yes | Das et al. (2008)
Delayed preputial separation | Gestational | CD-1 mouse, male | Yes | Das et al. (2008)

a See text for rationale for inclusion/exclusion from POD derivation.

b Both the Butenhoff et al. (2012a) and Das et al. (2008) studies were rated as high confidence.

#### Estimation or Selection of Points of Departure (PODs)

Consistent with EPA’s Benchmark Dose Technical Guidance U.S. EPA (2012), the BMD and 95% lower confidence limit on the BMD (BMDL) were estimated using a BMR to represent a minimal, biologically significant level of change. The BMD technical guidance U.S. EPA (2012) sets up a hierarchy by which BMRs are selected, with the first and preferred approach using a biological or toxicological basis to define what minimal level of response or change is biologically significant. If that biological or toxicological information is lacking, the BMD technical guidance recommends BMRs that can be used instead, specifically a BMR of 1 standard deviation (SD) from the control mean for continuous data or a BMR of 10% extra risk (ER) for dichotomous data. The BMRs selected for dose-response modeling of PFBA-induced health effects are listed in Table 5-2 along with the rationale for their selection.

Table 5-2 Benchmark response levels selected for benchmark dose (BMD) modeling of perfluorobutanoic acid (PFBA) health outcomes

Endpoint | BMR | Rationale
Liver
Increased relative liver weight | 10% relative deviation | A 10% increase in liver weight has generally been considered a minimally biologically significant response.
Increased liver hypertrophy | 10% extra risk | A 10% extra risk is a commonly used BMR for dichotomous endpoints U.S. EPA (2012) in the absence of information for a biologically based BMR; the endpoint is not considered a frank effect and does not support using a lower BMR.A 10% extra risk is a commonly used BMR for dichotomous endpoints U.S. EPA (2012) in the absence of information for a biologically based BMR; the endpoint is not considered a frank effect and does not support using a lower BMR.
Thyroid
Decreased total T4 | 1 standard deviation | Toxicological evidence that would support identification of a minimally biologically significant response is lacking in adult animals. Further, evidence for the level of response in thyroid hormones associated with neurodevelopmental effects is inconsistent, with decreases of 10%−25% identified in human and rodent studies (Gilbert et al., 2016; Gilbert, 2011; Haddow et al., 1999). The BMD technical guidance (U.S. EPA, 2012) recommends a BMR equal to 1 standard deviation for continuous endpoints when biological information is not sufficient to identify the BMR. In this case, the BMR based on 1 SD from the Butenhoff et al. (2012a) study corresponds to a ~13% decrease, consistent with the levels of decreased T4 associated with neurodevelopmental decrements, thus strengthening the rationale for using a BMR = 1 SD for this endpoint.
Developmental
Embryo/fetal morality | 1% extra risk | For quantal endpoints, the BMG Technical Guidance states “[f]from a statistical standpoint, most reproductive and developmental studies with nested study designs support a BMR of 5%” and “[b]iological considerations may warrant the use of a BMR of 5% or lower for some types of effects (e.g., frank effects) …”. As increased treatment-related embryo/fetal mortality is clearly a frank effect, BMRs of 5% and 1% were considered. Given that the study employed a nested design with individual animal data available that allow the use of the nested dichotomous models (to account for intra-litter similarity), and the effect of interest was a frank effect (supporting a BMR 5% or lower), a BMR of 1% extra risk was ultimately selected for derivation of the POD to account for the biological severity of these endpoints (i.e., mortality) and the robust statistical power of the study.
Delayed eye opening | 5% relative deviations | Biological evidence supports identification of a minimally significant decrease of visual input (1-d delayed eye opening) during a critical period of retinal development (Espinosa and Stryker, 2012). Delays of 1 d in eye opening reduces the time available for visual cortex development related to orientation selectivity by approximately 20% Espinosa and Stryker (2012) and corresponds to ~6% change in Das et al. (2008). Further, delays in vaginal opening greater than or equal to 2 d have been used previously to define biologically relevant responses U.S. EPA (2013), and this magnitude in delay in Das et al. (2008) is also ~6%. Both levels of response are consistent with a 5% relative deviation. Lastly, a 5% change in other markers of growth/development in gestational studies (e.g., fetal weight) has generally been considered a minimally biologically significant response level.
Delayed vaginal opening | 5% relative deviations
Delayed preputial separation | 5% relative deviations

When modeling was feasible, the estimated BMDLs were used as points of departure (PODs, see Table 5-4). Further details, including the modeling output and graphical results for the model selected for each endpoint, can be found in Appendix D. When dose-response modeling was not feasible, or adequate modeling results were not obtained, NOAEL or LOAEL values were identified based on biological rationales when possible and used as the POD. For example, for liver weight, a NOAEL would be chosen as the dose below which causes at least a 10% change, consistent with the rationale for the selecting the BMR for that endpoint. If no biological rationale for selecting the NOAEL/LOAEL is available, statistical significance was used as the basis for selection. The PODs (based on BMD modeling or NOAEL/LOAEL selection) for the endpoints advanced for dose-response analysis are presented in Table 5-4.

#### Approach for Animal-Human Extrapolation of Perfluorobutanoic Acid (PFBA) Dosimetry

The PFAS protocol (Appendix A) recommends the use of physiologically based pharmacokinetic (PBPK) models as the preferred approach for dosimetry extrapolation from animals to humans, while allowing for the consideration of data-informed extrapolations (such as the ratio of serum clearance values) for PFAS that lack a scientifically sound and sufficiently validated PBPK model. If chemical-specific information is not available, the protocol then recommends that doses be scaled allometrically using body weight (BW)^3/4^ methods. This hierarchy of recommended approaches for cross-species dosimetry extrapolation is consistent with EPA’s guidance on using allometric scaling for deriving oral reference doses (U.S. EPA, 2011). This hierarchy preferentially prioritizes adjustments that result in reduced uncertainty in the dosimetric adjustments (i.e., preferring chemical-specific values to underpin adjustments vs. use of default approaches).

No PBPK model is available for PFBA. But as pharmacokinetic data for PFBA exist in relevant animals (rats, mice, and monkeys) and humans, a data-informed extrapolation approach for estimating the dosimetric adjustment factor (DAF) can be used. Briefly, the ratio of the clearance (CL) in humans to animals, CL_H_:CL_A_, can be used to convert an oral dose rate in animals (mg/kg-day) to a human equivalent dose rate. Assuming the exposure being evaluated is low enough to be in the linear (or first-order) range of clearance, the average blood concentration (C_AVG_) that results from a given dose is calculated as:

C_AVG_ ( mg / mL ) = (f_abs_ × d o s e ( mg / kg / h ))/(C L ( mL / kg / h )) (5-1)

where f_abs_ is the fraction absorbed and dose is average dose rate expressed at an hourly rate.

If humans are exposed to a regular (daily) dose, D, then use of an estimated human clearance (CL_H_) leads to a prediction of an ongoing blood concentration equal to D/CL_H_; i.e., that is the steady-state or average blood concentration, C_AVG_, given the daily dose, D. Hence, this evaluation assumes that the steady-state level increases or decreases in direct proportion to D, with 1/CL_H_ being the proportionality constant.

Assuming equal toxicity given equal C_AVG_ in humans as mice or rats, and that f_abs_ is the same in humans as animals, the equitoxic dose (i.e., the human dose that should yield the same blood concentration [C_AVG_] as the animal dose from which it is being extrapolated) is then calculated as follows:

H E D = (P O D)/(C L_A_ / C L_H_) = P O D × (C L_H_)/(C L_A_) (5-2)

Thus, the DAF is simply CL_H_:CL_A_, the ratio of clearance in humans to clearance in the animal from which the POD is obtained. Note that although this evaluation of relative internal dose (C_AVG_) assumes that internal dose increases linearly with exposure (as does default allometric scaling), nonlinearity is usually observed only at relative high exposure levels. Further, although clearance of PFBA could be biphasic, it is still linear: A two-compartment classical PK model still uses all linear rate equations, and the predicted C_AVG_ from a two-compartment model still increases linearly with exposure or applied dose.

Clearance values, however, are not reported for humans in the one pharmacokinetic study available for PFBA (Chang et al., 2008). As clearance is a measure of average excretion, to calculate it, one also needs to evaluate a companion variable, the volume of distribution (V_d_), which in turn requires a measure of total exposure or dose. Chang et al. (2008) did not report the V_d_ for humans. Chang et al. (2008) did report V_d_ for cynomolgus monkeys, however, and as summarized above in Section 3.1.5, the data suggest a difference in V_d_ between rodents and monkeys. For comparison, the V_d_ values for PFOA and PFOS estimated from the PBPK parameters of Loccisano et al. (2011) are approximately 0.2 and 0.3 L/kg, respectively, although that obtained from monkeys for PFBA is approximately 0.5 L/kg. This value of V_d_ for PFBA was obtained from standard analysis of the empirical PK data, which is not influenced by any preliminary chemical-specific assumptions, but as stated by the authors, “Volume of distribution estimates indicated primarily extracellular distribution” (Chang et al., 2008). The difference between V_d_ for PFBA and those for PFOA and PFOS indicates slightly more intracellular distribution by PFBA. As described in Section 3.1.2 Distribution, V_d_ for humans is expected to be similar to the value for monkeys, thus the average value for male and female monkeys from Chang et al. (2008) will be used. Human clearance, normalized to body weight, can be calculated as follows:

C L_h u m a n_ ( mL / kg-h ) = In ( 2 ) × (1)/(t_1 / 2 , human_ ( h )) × V_d , monkey_ ( mL / kg ) (5-3)

Note that in equation (5-3), BW normalization is embedded in the fact that V_d_ is a volume per kg BW. For example, the average blood concentration, C_AVG_ (mg/mL), can then be estimated using equation (5-1) for any given dose (mg/kg/h = (mg/kg/d)/(24 h/d)), independent of specific BW.

As t_1/2_ is required in the calculation of CL, these values must be determined from the data presented for humans in (Chang et al., 2008). Chang et al. (2008) reported values for human subjects from two 3M facilities: Cottage Grove, Minnesota and Cordova, Illinois. Cottage Grove had three subjects, which were not identified by gender. Cordova had nine subjects, two of which were identified as female. The half-lives for those two women fell among the values of the other subjects (Cottage Grove and men from Cordova). Considering the minimal difference in t_1/2_ observed between male and female monkeys, the available data were assumed insufficient to distinguish male and female humans. The analytic method used replaced concentration measurements below the lower limit of quantitation (LLOQ) with LLOQ/√2. For individuals where only two measurements were made, the resulting half-life estimate was then highly sensitive to this assumption. The two known female subjects (Cordova), one male subject from Cordova, and one subject from Cottage Grove fell into this category; half-lives for these four subjects were not used. Additionally, the last time point for Subject 2 from Cottage Grove was below the LLOQ and was also excluded from t_1/2_ estimation. The mean and median t_1/2_ values estimated from these data (8 total subjects, 20 observations) were 81.8 and 67.5 hours, respectively. Mixed-effects modeling confirmed this half-life, estimating an approximate half-life of 67.9 hours when accounting for clustering (see Appendix C). Other details of the human half-life data are described in Section 3.1.4, Excretion.

As discussed in Section 3.1.4, using the common assumption of BW^0.75^ scaling of clearance and standard species BWs of 0.25 kg in rats and 80 kg in humans, the half-life in humans would be predicted to be 4.2 times greater than rats. Given half-lives of 9.22 and 1.76 hours in male and female rats, one would then predict half-lives of 38.7 hours in men and 7.4 hours in women. Although the value for men is in the range of results for humans, the value for women is much less than that estimated using the human data available from Chang et al. (2008). DAFs based on BW0^.75^ scaling for rats and a standard BW of 0.03 kg for mice are presented in Table 5-3. EPA’s guidance on use of BW0^.75^ as the default method for derivation of an oral reference dose states, however, “EPA endorses a hierarchy of approaches to derive human equivalent oral exposures from data from laboratory animal species.” It goes on to state that, although use of PBPK models is preferred, “Other approaches may include using chemical-specific information, without a complete physiologically-based pharmacokinetic model” (i.e., the approach described here, using relative clearance) and that use of BW0^.75 i^s endorsed, “In lieu of data to support either of these types of approaches” (U.S. EPA, 2011). Thus, because data are available to support a chemical-specific approach, it is clearly preferred.

Using a value of 484.5 mL/kg for V_d_ for humans [average of male and female V_d_ values in monkeys, 526 and 443 mL/kg, respectively, Table 4, Chang et al. (2008)] and 67.9 hours for t_1/2_ in male humans, CL in humans is estimated to be 4.95 mL/kg-hour = 0.12 L/kg-day. See Table 5-3 for the DAFs for converting rat and mice PODs to human equivalent doses (HEDs).

Table 5-3 Rat, mouse, and human clearance values and data-informed dosimetric adjustment factors

Sex | Species | Animal CL (mL/kg-h) | Human CL (mL/kg-h) | DAF (CL_H_:CL_A_) | DAF (BW0.75)^d^
Male | Rat | 21.61^a^ | 4.95^c^ | 0.229 | 0.236
Male | Mouse | 10.10^b^ | 4.95^c^ | 0.490 | 0.139
Female | Rat | 96.62^a^ | 4.95^c^ | 0.051 | 0.236
Female | Mouse | 27.93^b^ | 4.95^c^ | 0.177 | 0.139

Data from Tables 2, 3, 5, and 6 of Chang et al. (2008). Data from Tables 2, 3, 5, and 6 of Chang et al. (2008).

a Average of CL = dose/AUC (area-under-the-concentration-curve) was calculated using values reported for oral and i.v. exposures reported in Table 2 of Chang et al. (2008) see Table 3-2.

b Average of CL = dose/AUC was calculated using values reported for the 10- and 30-mg/kg dose groups reported in Table 3 of Chang et al. (2008) see Table 3-2. CL for the 100-mg/kg dose group was excluded, as it was ^~^threefold and ^~^twofold higher for males and females, respectively, than the values reported at 10 or 30 mg/kg. This could be due to saturation of renal absorption or serum binding.

c CL value for humans (male and female) as described above.

d DAFs based on assumption that elimination scales as BW^0.75^, hence clearance (elimination/BW) scales as BW^−0.25^, using standard BWs of 0.03, 0.25, and 80 kg for mice, rats, and humans, respectively.

Therefore, human equivalent dose (HED) for considered health effects was calculated as follows, using relative liver weight observed in male rats in the subchronic Butenhoff et al. (2012a) [underlined: study] as an example. Note that the concentration of the ammonium salt first needs to be converted to the concentration of the free acid before HED calculation:

H E D P F B A = P O D B H_4_^+^ PFB ( mg / kg-d ) (M W P F B A)/(M W N H_4_^+^ PFB) × (C L h u m a n ( m L / k g - h ))/(C L a n i m a l ( m L / k g - h )) H E D = 9.6 ( mg / kg-d ) × (214 g / m o l)/(231 g / m o l) × (4.95 ( mL / kg-h ))/(21.61 ( mL / kg-h )) = 2.04 ( mg / kg-d ) (5-4)

As discussed in Section 3.1.5 (Summary of Pharmacokinetics), the assumed linearity in PK (constant clearance) is likely to be valid for animal POD values of 30 mg/kg-day and below, but these DAFs should not be applied to higher PODs.

#### Uncertainty of Animal-to-Human Extrapolation of PFBA Dosimetry

There is uncertainty in applying this dosimetric approach given the volume of distribution (V_d_) was not measured in humans and the human V_d_ was assumed equal to that in monkeys to estimate clearance in humans. An alternative approach to using the ratio of clearance values for animal:human dosimetric adjustments is to use the measured serum concentrations from toxicological studies as BMD modeling inputs and then use the estimated human clearance values to calculate the HED. This approach, compared to the ratio of the clearance values approach, however, is interpreted to have even greater uncertainty. First, the measured serum concentrations were reported to have been taken 24 hours after the last exposure in the developmental toxicity study Das et al. (2008) and likely were similarly taken in the subchronic toxicity study (Butenhoff et al., 2012a; van Otterdijk, 2007a). Given the relatively short half-life of PFBA measured in mice and rats, this end-of-exposure measurement of serum concentrations likely did not reflect the average serum concentrations exposed animals experienced. For example, the reported serum levels (see Section 2.1.1) in female mice in the Das et al. (2008). Also, to estimate the HED without a validated PBPK model, the resulting POD (in units of serum concentrations) would need to be multiplied by the estimated human clearance value. Thus, in addition to the uncertainty in using end-of-exposure serum concentrations not reflective of average exposures, this approach would be characterized by the same uncertainty as the assumption that human and monkey volumes of distribution are equal and the uncertainty in the human half-life. Therefore, the ratio of clearance values is considered to have less uncertainty than either serum concentration-based BMD modeling or use of default allometric dosimetric adjustments. Thus, the approach based on clearance values is the one used here.

That only a single study reported PFBA PK data in rats or mice (or monkeys) introduces qualitative uncertainty, because these results were not validated in independent experiments. Results from different studies cannot be compared quantitatively. In the Chang et al. (2008) study, some results have relatively tight standard errors (SEs), indicating high confidence, but others (especially for mice), indicate high variability/uncertainty. Although the results for AUC in rats have relatively small SEs, they surprisingly show higher AUC (hence lower clearance) following oral doses than following i.v. doses (30 mg/kg). Oral absorption or bioavailability can range between near zero and 100%, but why the blood concentrations after an oral dose are higher than when the same dose is injected directly into the blood is puzzling. The data and plot of the PK model shown in Figures 1 and 2 of Chang et al. (2008) indicate the absorption and clearance phases are well characterized and described by the model, so the uncertainty does not appear to be due to the study design or analysis method. The almost twofold difference in clearance rates estimated from the oral vs. i.v. rat data thus indicate a comparable degree of uncertainty.

Compared to the results for rats, the Chang et al. (2008) clearance estimates at the two lower oral doses in male and female mice are much closer, with only an 8% difference between the two doses for males and a 16% difference for females. The results for both male and female mice show a dose-dependent increase in clearance across all dose levels, consistent with the hypothesis of saturable renal resorption. Although the increase only seems significant with the increase from 30 to 100 mg/kg, the differences between 10 and 30 mg/kg could result from the same mechanism. Thus, those differences might reflect a biological mechanism as much as experimental or analytic variability. The lack of i.v. data in mice at the same dose as any of the oral doses, however, means that one cannot fully compare the apparent self-consistency of the mouse data to the inconsistency noted above for rats.

If the oral vs. i.v. discrepancy in rats is interpreted as indicating an overall factor of 2 uncertainty in the animal clearance values, that can be considered a moderate degree of uncertainty. ORD’s Umbrella quality assurance project plan (QAPP) for dosimetry and mechanism-based models (U.S. EPA, 2020) states that PBPK models are expected to match the corresponding data within a factor of 2 to be considered sufficient for use in risk assessment and similarly IPCS (2010) states that PBPK models can be considered adequate when predictions that are, on average, within a factor of two of experimental data. Hence, this level of uncertainty is considered acceptable in PK analyses. Although the human half-life estimates vary just over fivefold from highest to lowest, this much variability in a human population is not surprising, and with results from just 12 subjects to characterize the mean, uncertainty in that mean can, again, be considered moderate. Given that the physiological fractions of different tissue types is similar in humans and primates and that the blood serum:tissue portioning is reasonably expected to be similar across mammals, the assumption that the volume of distribution in humans is similar to monkeys is considered to have low uncertainty. Considering all these factors, the overall uncertainty in HED calculations using equation (5-4) with the parameters estimated here is considered moderate, that is, within a factor of 3.

#### Application of Animal-Human Extrapolation of PFBA Dosimetry

Table 5-4 presents the PODs and estimated POD_HED_ values for the thyroid, liver, and developmental toxicity endpoints.

Table 5-4 Points of departure (PODs) considered for use in deriving candidate reference values for perfluorobutanoic acid (PFBA)

Endpoint/reference | Species/strain /sex | POD type/model | POD NH_4_^+^ PFB (mg/kg-d) | POD PFBA (mg/kg-d)^a^ | POD_HED_ PFBA^b^ (mg/kg-d)
Increased relative liver weight; Butenhoff et al. (2012a) | S-D rat, male | BMDL_10RD_ Exp3 (LN-CV) | 9.6 | 8.89 | 2.04
Increased relative liver weight; Das et al. (2008) | CD-1 mouse, P_0_ female | BMDL_10RD_ Exp4 (CV) | 15 | 13.9 | 2.46
Increased liver hypertrophy; Butenhoff et al. (2012a) | S-D rat, male | NOAEL^b^ (0% response) | 6 | 5.56 | 1.27
Decreased total T4; Butenhoff et al. (2012a) | S-D rat, male | NOAEL^c^ (15% decrease) | 6 | 5.56 | 1.27
Embryo/fetal mortality^d^; Das et al. (2008) | CD-1 mouse, F_1_ male/female | BMDL_1ER_ Nested-Logistic | 5.7 | 5.28 | 0.93
Delayed eyes opening^d^; Das et al. (2008) | CD-1 mouse, F_1_ male/female | BMDL_5RD_ Hill (CV) | 4.9 | 4.54 | 0.80
Delayed vaginal opening^d^; Das et al. (2008) | CD-1 mouse, F_1_ female | BMDL_5RD_ Hill (CV) | 3.8 | 3.52 | 0.62
Delayed preputial separation^d^; Das et al. (2008) | CD-1 mouse, F_1_ male | BMDL_5RD_ Exp3 (CV) | 179.1 | 165.92 | n/a^e^

BMDL = 95% lower limit on benchmark dose, RD = relative deviation, LN = log-normal, CV = constant variance, ER = extra risk, NOAEL = no-observed-adverse-effect level.

a Both of these studies used the ammonium salt of PFBA as the test article. To calculate a POD for the free acid of PFBA from any PFBA salt, multiply the POD of interest by the ratio of molecular weights of the salt and the free acid. For example, to convert from the ammonium salt of PFBA to the free acid, multiply the ammonium salt POD by

(M W f r e e a c i d)/(M W a m m o n i u m s a l t) = (214)/(231) = 0.926

.

See discussion in Section 5.2.1, Approach for Animal-Human Extrapolation of PFBA Dosimetry, for details on HED.

b NOAEL approach used as responses are only seen in the high dose group at levels much higher (90%) than the BMR.

c No models provided adequate fit to the mean when using constant or nonconstant variance with the normal distribution or constant variance with the log-normal distribution.

d All HED calculations used DAF for female mice, given exposures were to pregnant animals.

e As noted previously, linearity in clearance values is only valid up to approximately 30 mg/kg-d and the DAF based on a ratio of clearance values should not be applied to PODs greater than 30 mg/kg-d. Therefore, given that the POD for preputial separation is above this limit, and other PODs are below that limit, preputial separation is not considered further for use in estimating a candidate toxicity value for developmental delays. Instead, PODs for delays in vaginal opening and eye opening are advanced for this purpose.

#### Derivation of Candidate Toxicity Values for the Oral Reference Dose (RfD)

Under EPA’s A Review of the Reference Dose and Reference Concentration Processes U.S. EPA (2002) and Methods for Derivation of Inhalation Reference Concentrations and Application of Inhalation Dosimetry U.S. EPA (1994), five possible areas of uncertainty and variability were considered in deriving the candidate values for PFBA. An explanation of these five possible areas of uncertainty and variability and the values assigned to each as designated UFs to be applied to the candidate POD_HED_ values are listed in Table 5-5. As discussed below, the short-term studies of thyroid and hepatic effects after PFBA exposure were considered for use in UF selection.

Table 5-5 Uncertainty factors for the development of the candidate values for perfluorobutanoic acid (PFBA)

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^ = 3.16 ^~^3) is applied to account for uncertainty in characterizing the pharmacokinetic and pharmacodynamic differences between mice or rats and humans following oral NH_4_^+^PFB/PFBA exposure. Some aspects of the cross-species extrapolation of pharmacokinetic processes have been accounted for by calculating an HED through application of a DAF based on animal and human half-lives; however, some residual pharmacokinetic uncertainty and uncertainty regarding pharmacodynamics remains. Available chemical-specific data further support the selection of a UF of 3 for PFBA; see text below for further discussion.
UF_H_ | 10 | A UF_H_ of 10 is applied for interindividual variability in the absence of quantitative information on the pharmacokinetics and pharmacodynamics of NH_4_^+^PFB/PFBA in humans.
UF_S_ | 10; 1 | A UF_S_ of 10 is applied to endpoints observed in the subchronic study Butenhoff et al. (2012a); van Otterdijk (2007a) for the purposes of deriving chronic toxicity values. See additional discussion on this decision below.; A UF_S_ of 1 is applied to endpoints observed in the developmental toxicity study Das et al. (2008) the developmental period is recognized as a susceptible lifestage where exposure during certain time windows (e.g., pregnancy and gestation) is more relevant to the induction of developmental effects than lifetime exposure (U.S. EPA, 1991).
UF_L_ | 1 | A UF_L_ of 1 is applied for LOAEL-to-NOAEL extrapolation when the POD is a BMDL or NOAEL.
UF_D_ | 3 | A UF_D_ of 3 is applied because, although the PFBA database is relatively small, high confidence subchronic and developmental toxicity studies are available in mice and rats. Although these high confidence studies are available for PFBA, the database has some deficiencies, including the lack of information on developmental neurotoxicity and other endpoints; see the text below for further discussion.
UF_C_ | Table 5-7 | Composite uncertainty factor = UF_A_ × UF_H_ × UF_S_ × UF_L_ × UF_D_.

As described in EPA’s A Review of the Reference Dose and Reference Concentration Processes U.S. EPA (2002), the interspecies uncertainty factor (UF_A_) is applied to account for extrapolation of animal data to humans; it accounts for uncertainty regarding the pharmacokinetic and pharmacodynamic differences across species. As is usual in the application of this uncertainty factor, the pharmacokinetic uncertainty is mostly addressed through the application of dosimetric approaches for estimating human equivalent doses (see Section 4.2.2). This leaves some residual uncertainty around the pharmacokinetics and the uncertainty surrounding pharmacodynamics. Typically, a threefold UF is applied for this uncertainty in the absence of chemical-specific information. This is the case for the thyroid and developmental endpoints. For the liver endpoints, chemical-specific information should be considered further in determining the most appropriate value for the UF_A_ to account for the uncertainty.

Foreman et al. (2009) investigated the response to PFBA exposure in PPARα wild-type, PPARα null, and hPPARα mice for hepatic effects and observed either that effects were generally equivalent in wild-type vs. humanized mice (liver weight, liver hypertrophy, see Table 3-6 and Table 3-7), that wild-type mice exhibited effects that humanized mice did not (focal hepatic necrosis, based on statistical significance), and that PPARα null mice generally did not exhibit hepatic effects except for vacuolation. Additionally, in vitro studies suggest that human cells or cells transfected with human PPARα were less sensitive to PPAR activation than rodent cells or rodent PPARα (Rosen et al., 2013; Wolf et al., 2012; Bjork and Wallace, 2009; Wolf et al., 2008). If PPARα were the only operant MOA for noncancer effects in the liver, this observation might support reducing the remaining portion of the UF_A_ to 1, as it could be argued that humans are not as sensitive as wild-type rats to the hepatic effects of PFBA exposure (note: without evidence to the contrary, as mentioned in the previous paragraph, the pharmacodynamic portion of this UF is typically assigned a value of 3 assuming responses manifest in humans could be more sensitive than those observed in animals). Additional evidence presented in Foreman et al. (2009) and other studies (see Section 3.2.2), however, indicates that non-PPARα MOAs appear to be active in the livers of exposed rats. Specifically, from Foreman et al. (2009) vacuolation is reported in the livers of PPARα null and humanized mice, but not in wild-type mice, although the degree to which null or humanized mice are more susceptible to this effect is difficult to characterize given the results are presented qualitatively. Vacuolation (i.e., the accumulation of lipids) is an important precursor event in the development of steatosis, which itself is a precursor to other adverse conditions such as steatohepatitis, fibrosis, and cirrhosis. As discussed in Section 3.2.2, this observation of PFBA-induced effects independent of PPARα activation is supported by in vitro and in vivo data that show other PFAS can activate other forms of PPAR (i.e., PPARγ) and additional pathways (i.e., constitutive androstane receptor [CAR] or pregnane X receptor [PXR]). Given the observation of apical liver effects in humanized PPARα mice and the observation that other MOAs appear to contribute to potential liver toxicity, the observation that humanized PPARα mice exhibit diminished responses for some hepatic effects attributable to PPARα activation cannot alone determine the appropriate value of the pharmacodynamic portion of the UF_A_. Therefore, given the remaining uncertainty in additional MOAs that appear active in PFBA-induced liver effects, and the relative contribution of these MOAs to toxicity in humans as compared with rodents, the value of UF_A_ was set to 3 for the purposes of deriving toxicity values for hepatic effects. No MOA information is available for thyroid or developmental effects; in the absence of information suggesting otherwise, as noted above, a UF_A_ (3) is also applied to these endpoints to account for any residual pharmacokinetic and pharmacodynamic uncertainty.

The short-term studies of Butenhoff et al. (2012a), van Otterdijk (2007a), and Foreman et al. (2009) were considered for potential use in informing the selection of the UFS. More specifically, for several outcomes from which PODs were derived, comparisons between short-term exposure and subchronic exposure appeared possible (i.e., because of the inherent similarities in study design and experimental conduct). When comparing short-term to subchronic PFBA exposure for liver weight and thyroid hormone measures, there was no apparent increased sensitivity with longer exposure duration in terms of the magnitude of the observed effects at the same tested doses or the lowest doses at which effects were observed. In addition, given the pharmacokinetics of PFBA, steady-state levels in potential target tissues might not substantially increase with increasing exposure duration (Butenhoff et al., 2012a; van Otterdijk, 2007a, b). In these studies, the latter conclusion seemed dose dependent, as PFBA levels actually decreased with longer exposures when comparisons are made at 6 mg/kg-day (~25 to 14 µg/mL in serum and ~7.5 to 3.1 µg/g in liver comparing 28 to 90 days of exposure), whereas levels were either increased slightly or were similar when comparisons are made at 30 mg/kg-day (~38 to 52 µg/mL in serum and ~17.4 to 16.1 µg/mL in liver comparing 28 to 90 days of exposure). This indicates perhaps that steady-state conditions have been reached in the livers of exposed rats after only 28 days of exposure. Preliminarily, this indicates that increased durations of exposure might not elicit increased effects in the target tissue, as the LOAEL for liver weights is 30 mg/kg-day for male rats exposed to either 28 or 90 days. When also considering results from the 28-day exposure study by Foreman et al. (2009) and the gestational exposure study by Das et al. (2008) basing comparisons on human equivalent external concentrations (see Table 5-6 below for modeling results and application of dosimetric adjustments), liver weight appears affected at similar doses across mice and rats across these three different exposure durations (i.e., gestational, short-term, and subchronic). However, it should be noted that these data indicating no increase of effect when comparing subchronic exposures to short-term exposures (an increase in duration of approximately 3-fold) is not considered sufficient evidence to convincingly argue that effects would not worsen following chronic exposures (an increase of approximately 8-fold increase in duration, compared to subchronic). While it is true that pharmacokinetic data suggests liver concentrations may reach steady-state conditions rapidly (i.e., following 28 days of exposure), it is reasonable to assume that prolonged exposure to those levels of tissue-specific concentrations over the course of multiple years could result in an increased magnitude of effect or effects evident at lower doses. Contributing to this assumption is the consideration of the impact of PFBA exposure duration on related liver effects.

In fact, the lack of increasing effect with increasing duration is not the case for all liver effects. Histopathological evaluations of the liver in male rats exposed to PFBA for 90 days show that hepatocellular hypertrophy occurs at 30 mg/kg-day, whereas hypertrophy occurs only at 150 mg/kg-day in male rats exposed for 28 days (Butenhoff et al., 2012a; van Otterdijk, 2007a, b). Thus, although liver concentrations are equivalent following 28- or 90-day exposures, that prolonged exposure (i.e., 90 days vs. 28 days) elicits adverse effects in the liver is readily apparent. Taking into account the increased potential for some effects in the liver with increasing durations of exposure, and the large uncertainty associated with the lack of data on whether the effects observed in the subchronic study worsen after chronic exposure, the UF_S_ were therefore set to 10 for the purposes of the liver endpoints.

Table 5-6 Comparison of liver-weight effects across species and durations of exposure

Reference | Species/strain/sex | Duration | POD type/model | POD NH_4_^+^ PFB (mg/kg-d) | POD PFBA (mg/kg-d) | POD_HED_ PFBA (mg/kg-d)
Relative liver weight; Butenhoff et al. (2012a) | S-D rat, male | 90 d | BMDL_10RD_ Exp3 (LN-CV) | 9.6 | 8.89 | 2.04
Relative liver weight; Butenhoff et al. (2012a) | S-D rat, male | 28 d | BMDL_10_, Exp4 (NCV) | 6.34 | 5.87 | 1.3
Relative liver weight; Foreman et al. (2009) | Sv/129 WT mouse, male | 28 d | LOAEL^a^ | 35 | 32.42 | 1.59^b^
Relative liver weight; (Foreman et al., 2009) | Sv/129 hPPARα mouse, male | 28 d | BMDL_10_, Hill (NCV) | 4.41 | 4.09 | 2.00
Relative liver weight; Das et al. (2008) | CD-1 mouse, P_0_ female | Gestational | BMDL_10RD_ Exp4 (CV) | 15 | 13.9 | 2.46

a Data is highly supralinear and BMD modeling guidance recommends against modeling this type of dose-response pattern.

b As this data set only supported identification of a LOAEL, the LOAEL-to-NOAEL uncertainty factor was applied to facilitate comparison to the other HEDs for liver-weight effects.

Regarding thyroid endpoints, effects on total T4 following subchronic exposures were not worse compared to effects following 28-day exposures in the Butenhoff et al. (2012a) study. owever, for thyroid hypertrophy/hyperplasia, although total incidence of hypertrophy/hyperplasia was not observed to worsen with increasing duration (the LOAEL was 30 mg/kg-day for both exposure durations), there is evidence that the severity of the observed lesions worsened after 90-day exposures. As Table 3-4 shows, nine out of ten animals developed thyroid hypertrophy/hyperplasia following 28-day exposures, with all animals displaying minimally severe lesions. However, following 90-day exposures, while the total incidence was the same (9/10), four animals had minimally severe lesions while 5 animals developed mild lesions. While not conclusive, this evidence suggests that damage to the thyroid organ specifically might worsen with increasing duration. Given this potential concern for more severe effects on the thyroid with longer exposures and the small number of studies (e.g., one) available to inform this interpretation for either thyroid histopathology or levels of circulating THs, the default UF_S_ of 10 was also retained for thyroid endpoints.

As described in EPA’s A Review of the Reference Dose and Reference Concentration Processes U.S. EPA (2002), the database uncertainty factor is applied to account for the potential of deriving an underprotective reference value as a result of incomplete characterization of a chemical’s toxicity. The PFBA database is relatively small but contains high confidence subchronic and developmental toxicity studies investigating effects in multiple organ systems in male and female rats and mice.

For PFBA, given the small number of available studies, both a UF_D_ = 10 or a UF_D_ = 3 were considered due to the limited database (most specifically the lack of a two-generation developmental/reproductive toxicity study, but also a lack of studies on potential neurodevelopmental or developmental immune effects), and a UF_D_ = 3 ultimately was applied. Typically, the specific study types lacking in a chemical’s database that influence the value of the UF_D_ to the greatest degree are developmental toxicity and multigenerational reproductive toxicity studies. The PFBA database does include a high confidence Das et al. (2008) developmental toxicity study in mice. Despite its quality, however, that study fails to cover endpoints related to potential transgenerational impacts of longer-term exposures evaluated in a two-generation study. The 1994 Reference Concentration Guidance U.S. EPA (1994) and 2002 Reference Dose Report U.S. EPA (2002) support applying a UF_D_ in situations when such a study is missing. The 2002 Reference Dose Report U.S. EPA (2002) states that “[i]f the RfD/RfC is based on animal data, a factor of 3 is often applied if either a prenatal toxicity study or a two-generation reproductive study is missing.” Consideration of the PFBA, PFBS (a short-chain perfluoroalkane sulfonic acid with a 4-carbon backbone like PFBA), PFHxA (a short-chain perfluoroalkyl carboxylic acid; see public comment draft for PFHxA; ),^13^ and PFHxS (a long-chain perfluoroalkane sulfonic acid) databases together, however, diminish the concern that the availability of a multigenerational reproductive study would result in reference values lower than those currently derived for PFBA. Although limited in their ability to assess reproductive health or function, measures of possible reproductive toxicity, including reproductive organ weights (i.e., epididymis, testis, and ovary weights) were unaffected when measured after exposure to PFBA for 28 days (Butenhoff et al., 2012a; van Otterdijk, 2007a). Likewise, the available data on reproductive toxicity in the PFBS database is consistent with this general lack of sensitive reproductive effects: No biologically significant changes were observed in male mating and fertility parameters, reproductive organ weights, reproductive hormone levels, or altered sperm parameters (U.S. EPA, 2018b). The female reproductive effects that were observed (e.g., altered estrous cyclicity) occurred at doses equal to or higher than those that resulted in effects in other organ systems (e.g., thyroid, liver), thus indicating they were not more sensitive markers of toxicity. Further, no notable male or female reproductive effects were observed in epidemiological or toxicological studies investigating exposure to PFHxA (see public comment draft for PFHxA, (U.S. EPA, 2021b) and (Luz et al., 2019; NTP, 2019; Klaunig et al., 2015; Chengelis et al., 2009) or PFHxS (MDH, 2019). Therefore, when considering the limited chemical-specific information alongside information gleaned from structurally related compounds, the lack of a multigenerational reproductive study is not considered a major concern relative to UF_D_ selection.

Another gap in the PFBA database is the lack of measures of thyroid toxicity in gestationally exposed offspring and the lack of a developmental neurotoxicity study. The potential for neurodevelopmental effects, whether thyroid hormone-dependent or independent, remains an uncertainty for PFBA. Thyroid hormones are critical in myriad physiological processes and must be maintained at sufficient levels during times of brain development in utero and after birth. Although no PFBA-specific data on thyroid hormone levels following gestational exposure are available, total T4 is reduced in both pregnant mice and their offspring following whole-gestation oral exposure to PFBS, with effects evident in offspring at PNDs 1, 30, and 60. Therefore, anticipating that effects due to PFBA exposure also could have been observed had thyroid hormone levels been measured in the Das et al. (2008) developmental study is reasonable. For PFBS, the PODs for effects in dams and offspring on PND 1 were almost identical, indicating that thyroid hormone homeostasis is perturbed at equivalent exposure levels in both pregnant animals and developing offspring. Thus, although some concern remains that thyroid insufficiency during in utero and perinatal development could be a more sensitive effect of PFBA exposure than insufficiency in adults, this concern is mitigated on the basis of data from other PFAS. Likewise, given that neurodevelopmental effects due to thyroid hormone insufficiency would be downstream effects, application of a UF_D_ (and derivation of reference values) addressing the potential for developmental thyroid insufficiency would presumably be protective of any potential neurodevelopmental endpoints related to that mechanism. The potential for neurodevelopmental effects independent of a thyroid hormone-related mechanism remains an uncertainty for PFBA.

Lastly, the potential for immunotoxicity (including developmental immunotoxicity, in particular) and mammary gland effects represents an area of concern across several constituents of the larger PFAS family (primarily long-chain PFAS). No studies have evaluated these outcomes following PFBA oral exposure or following oral exposure to the structurally related PFBS described above. However, one dermal toxicity study Weatherly et al. (2021) did observe altered cellularity for multiple immune cell types in the draining lymph nodes and ear pinna of exposed animals, raising the concern for immunotoxicity following oral exposures. However, without reported internal serum levels, it is difficult to ascertain whether the exposure levels in the dermal study are equipotent to the oral exposures used in the subchronic and developmental toxicity studies and whether the hepatic, thyroid, or developmental endpoints observed in those studies would be protective of immunotoxicity endpoints. Overall, no chemical-specific information is available to judge the degree to which the existing endpoints in the PFBA Toxicological Review would be protective of mammary gland or immune (including developmental immune) effects after oral exposure.

Given the residual concerns for potentially more sensitive effects outlined above, a database uncertainty factor is considered necessary. Specifically, a value of 3 was selected for the UF_D_ to account for the uncertainty surrounding the lack of a multigenerational reproductive study, developmental neurotoxicity study (or information on thyroid hormone perturbation in utero and postnatally), immunotoxicity (and developmental immunotoxicity, in particular), or mammary gland effects. A UF_D_ of 10 was not applied, given that multiple lines of chemical-specific information or data from structural analogs are available to partially mitigate the concern that additional study would possibly result in reference values one order of magnitude lower than the one currently derived. Thus, a UF_D_ value of 3 was applied because currently available lines of evidence do not fully eliminate this concern.

The candidate values (see Table 5-7) are derived by dividing the POD_HED_ by the composite uncertainty factor. For example, for relative liver weight in adult rats from Butenhoff et al. (2012a), the candidate value is calculated as:

candidate value for PFBA = BMDL_10_ ÷ UF_c_ candidate value = 2.04 ( (mg)/(kg-d) ) ÷ 1,000 candidate value = 0.002 ( (mg)/(kg-d) ) candidate value = 2.0 × 10^− 3^ ( (mg)/(kg-d) ) (5-5)

Table 5-7 Candidate values for perfluorobutanoic acid (PFBA)

Endpoint | POD_HED_ PFBA (mg/kg-d) | UF_A_ | UF_H_ | UF_S_ | UF_L_ | UF_D_ | UF_C_ | Candidate value PFBA (mg/kg-d) | Candidate value NH_4_^+^ PFB (mg/kg-d)^a^
Increased relative liver weight; Butenhoff et al. (2012a) | 2.04 | 3 | 10 | 10 | 1 | 3 | 1,000 | 2.0 × 10^−3^ | 2.2 × 10^−3^
Increased relative liver weight; Das et al. (2008) | 2.46 | 3 | 10 | 10 | 1 | 3 | 1,000 | 2.5 × 10^−3^ | 2.7 × 10^−3^
Increased liver hypertrophy; Butenhoff et al. (2012a) | 1.27 | 3 | 10 | 10 | 1 | 3 | 1,000 | 1.3 × 10^−3^ | 1.4 × 10^−3^
Decreased total T4; Butenhoff et al. (2012a) | 1.27 | 3 | 10 | 10 | 1 | 3 | 1,000 | 1.3 × 10^−3^ | 1.4 × 10^−3^
Embryo/fetal mortality; Das et al. (2008) | 0.93 | 3 | 10 | 1 | 1 | 3 | 100 | 9.5 × 10^−3^ | 1.0 × 10^−2^
Delayed eyes opening; Das et al. (2008) | 0.80 | 3 | 10 | 1 | 1 | 3 | 100 | 8.0 × 10^−3^ | 8.6 × 10^−3^
Delayed vaginal opening; Das et al. (2008) | 0.62 | 3 | 10 | 1 | 1 | 3 | 100 | 6.2 × 10^−3^ | 6.7 × 10^−3^

a To calculate candidate values for salts of PFBA, multiply the candidate value of interest by the ratio of molecular weights of the free acid and the salt. For example, for the ammonium salt of PFBA, the RfD would be calculated by multiplying the free acid RfD by (M W a m m o n i u m s a l t)/(M W f r e e a c i d) = (231)/(214) = 1.079 . This same conversion can be applied to other salts of PFBA, such as the potassium or sodium salts.

#### Selection of Lifetime Toxicity Value(s)

##### Selection of organ/system-specific oral reference doses (osRfDs)

From among the candidate values presented in Table 5-7, organ/system-specific RfDs (osRfDs) are selected for the individual organ systems identified as hazards in Section 3. The osRfD values selected were associated with increased liver hypertrophy for liver effects, decreased total T4 for thyroid effects, and developmental delays (based on the candidate value for delayed time to vaginal opening) for developmental effects. The confidence decisions about the study, evidence base, quantification of the POD, and overall RfD for these organ/system-specific values are fully described in Table 5-8, along with the rationales for selecting those confidence levels. In deciding overall confidence, confidence in the evidence base is prioritized over the other confidence decisions. The overall confidence in the osRfD for liver effects is medium, whereas the confidence in the osRfDs for thyroid effects and developmental effects is medium-low. Selection of the overall RfD is described in the following section.

Table 5-8 Confidence in the organ/system-specific oral reference doses (osRfDs) for perfluorobutanoic acid (PFBA)

Confidence categories | Designation | Discussion
Liver RfD = 1 × 10^−3^ mg/kg-d PFBA; 1 × 10^−3^ mg/kg-d NH_4_^+^ PFB
Confidence in study^a^ used to derive osRfD | High | Confidence in the study Butenhoff et al. (2012a); van Otterdijk (2007b) is high given the study evaluation results (i.e., rating of good or adequate in all evaluation categories) and characteristics that make it suitable for deriving toxicity values, including the relevance of the exposure paradigm (route, duration, and exposure levels), use of a relevant species, and the study size and design.
Confidence in evidence base supporting this hazard | Medium | Confidence in the evidence base for liver effects is medium because there are consistent, dose-dependent, and biologically coherent effects on organ weight and histopathology observed in multiple high and medium confidence studies. Although the available mechanistic evidence also supports the human relevance of observed effects, there is a sparsity of chemical-specific information. One in vivo PFBA study Foreman et al. (2009) is available that indicates non-PPARα modes-of-action are active in the development of liver effects, but no PFBA-specific studies investigated activation of other PPAR isoforms or additional pathways. Another limitation of the database for PFBA-induced liver effects is the lack of a chronic duration study.
Confidence in quantification of the POD_HED_ | Medium | Confidence in the quantification of the POD and osRfD is medium given the POD was based on a NOAEL (BMD modeling not supported given that responses are only observed in the high dose group at levels (90%) much greater than the BMR) and dosimetric adjustment was based on PFBA-specific pharmacokinetic information, the latter of which introduces some uncertainty. Generally, the use of a NOAEL for the POD would result in a reduced confidence rating. However, in this case, the NOAEL of 6 mg/kg-d is very close to the BMDL (5.4 mg/kg-d) that would be selected had BMD modeling been supported. Therefore, this NOAEL is not interpreted as likely to be substantially more uncertain than a BMD-based POD. This supports a determination that the confidence in the quantification of the POD is medium.
Overall confidence in osRfD | Medium | The overall confidence in the osRfD is medium and is primarily driven by medium confidence in both the evidence base supporting this hazard and the quantification of the POD from a high confidence study.
Thyroid RfD = 1 × 10^−3^ mg/kg-d PFBA; 1 × 10^−3^ mg/kg-d NH_4_^+^ PFB
Confidence in study^a^ used to derive osRfD | High | Confidence in the study Butenhoff et al. (2012a); van Otterdijk (2007b) is high given the study evaluation results (i.e., rating of good or adequate in all evaluation categories) and characteristics that make it suitable for deriving toxicity values, including the relevance of the exposure paradigm (route, duration, and exposure levels), use of a relevant species, and the study size and design.
Confidence in evidence base supporting this hazard | Medium | Confidence in the evidence base for thyroid effects is medium because there were consistent and coherent effects on hormone levels, organ weights, and histopathology in a single high confidence study. Confidence is decreased by the lack of coherence between histopathology and TSH, as well as the increased sensitivity of rodents for developing thyroid hypertrophy compared to humans. Another limitation of evidence base for thyroid effects is the lack of a chronic-duration or developmental study.
Confidence in quantification of the POD_HED_ | Medium-low | Confidence in the quantification of the POD and osRfD is medium-low given the POD was based on a NOAEL (BMD modeling did not provide an adequate fit to the data) and dosimetric adjustment was based on PFBA-specific pharmacokinetic information, the latter of which introduces some uncertainty. Although a 15% decrease in total T4 levels, upon which the NOAEL was based, is consistent with a 13% decrease in total T4 that would correspond to a response level at a BMR of 1 SD (i.e., the BMD), there is uncertainty regarding how much lower a BMDL would be as compared to the NOAEL^b^. Therefore, while this NOAEL is not likely to be substantially more uncertain than a BMD, it is higher than a BMDL-based POD would be. This introduces some additional uncertainty and supports a determination that the confidence in the quantification of the POD is medium-low.
Overall confidence in osRfD | Medium-low | The overall confidence in the osRfD is medium-low and is primarily driven by medium confidence in the evidence base; however, the medium-to-low confidence in the quantification of the POD does warrant decreasing the overall confidence in the osRfD.
Developmental RfD = 6 × 10^−3^ mg/kg-d PFBA; 7 × 10^−3^ mg/kg-d NH_4_^+^ PFB
Confidence in study^a^ used to derive osRfD | High | Confidence in the study Das et al. (2008) is high given the study evaluation results (i.e., rating of good or adequate in all evaluation categories) and characteristics that make it suitable for deriving toxicity values, including the relevance of the exposure paradigm (route, duration, and exposure levels), use of a relevant species, and the study size and design.
Confidence in evidence base supporting this hazard | Medium | Confidence in the evidence base for developmental effects is medium. Although data are only available in gestationally exposed animals in a single high confidence developmental toxicity study, there were coherent delays in multiple developmental milestones (general and reproductive development).
Confidence in quantification of the POD_HED_ | Medium-low | Confidence in the quantification of the POD and osRfD is medium-to-low given the POD was based on BMD modeling and dosimetric adjustment was based on PFBA-specific pharmacokinetic information, the latter of which introduces some uncertainty. Other sources of uncertainty are the use of dosimetric adjustments based on the ratio of adult pharmacokinetic parameters, and that the derived BMDL is approximately ninefold below the observed range of the data.
Overall confidence in osRfD | Medium-low | The overall confidence in the osRfD is medium-low and is primarily driven by the medium-to-low confidence in the quantification of the POD given the extrapolation below the range of the observed data. Modeling data from a high confidence study in a medium-confidence evidence base does not fully mitigate the medium-to-low confidence in the actual modeling results in this case.

a All study evaluation details can be found on HAWC.

b Note that the BMDL would be considerably less than an order of magnitude lower given that the next lower dose tested was only 5-fold lower than the NOAEL and a non-significant increase in T4 was observed at that dose.

##### Selection of overall oral reference dose (RfD) and confidence statement

Organ/system-specific RfD values for PFBA selected in the previous section are summarized in Table 5-9.

Table 5-9 Organ/system-specific oral reference dose (osRfD) values for perfluorobutanoic acid (PFBA)

System | Basis | POD | UFc | osRfD PFBA (mg/kg-d) | osRfD NH_4_^+^ PFB (mg/kg-d)^b^ | Confidence
Hepatic | Increased hepatocellular hypertrophy in adult male S-D rats | BMDL_HED_ from Butenhoff et al. (2012a) | 1,000 | 1 × 10^−3^ | 1 × 10^−3^ | Medium
Thyroid | Decreased total T4 in adult male S-D rats | NOAEL_HED_ from Butenhoff et al. (2012a) | 1,000 | 1 × 10^−3^ | 1 × 10^−3^ | Medium-low
Developmental | Developmental delays after gestational exposure in CD1 mice^a^ | BMDL_HED_ from Das et al. (2008) | 100 | 6 × 10^−3^ | 7 × 10^−3^ | Medium-low

a POD based on delayed vaginal opening used to represent three developmental delays observed in the study.

b See Table 5-7 for details on how to calculate candidate values for salts of PFBA; the osRfDs presented in this table have been rounded to 1 significant digit from the candidate values presented in Table 5-7.

From the identified human health hazards of PFBA exposure and the derived osRfDs for effects in the liver, thyroid, and developing organism, an overall RfD of 1 × 10^−3^ mg/kg-day PFBA based on increased liver hypertrophy and decreased total T4 is selected. The selected RfD for the ammonium salt of PFBA is also 1 × 10^−3^ mg/kg-day. These osRfDs are selected as the overall RfD as they represent effects in two different organ systems with the same osRfD value., including the osRfD with the highest confidence of all osRfDs derived (i.e., the hepatic osRfD, with medium confidence). The other available osRfD (for developmental effects) was interpreted with medium-low confidence and had a higher osRfD value; thus, it was not selected. Although the overall confidence in the individual liver and thyroid osRfDs do differ slightly (medium for increased liver hypertrophy and medium-low for decreased total T4), an overall confidence of medium is selected for the final RfD. This confidence level of medium is supported given the two osRfDs come from the same high confidence study and that the evidence bases for both organ systems were rated as medium. The difference in the overall confidence for the two osRfDs was driven primarily by the confidence in the quantification of the POD_HED_s: medium for increased liver hypertrophy and medium-low for decreased total T4. As noted in Table 5-8, the medium-low confidence in the thyroid POD_HED_ reflects that the selected NOAEL would be greater than the BMDL that would be derived if BMD modeling were possible, although this difference would be considerably less than an order of magnitude (see Table 5-8) which reduces the level of concern for this uncertainty. This uncertainty is further mitigated when taken together with the medium confidence in the POD_HED_ for the co-critical effect on the liver. Altogether, this supports the determination of medium confidence in the overall RfD based on liver and thyroid effects.

Another consideration in selecting the overall RfD is the difference in composite uncertainty factors across the three candidate osRfDs. The composite UF for the liver and thyroid osRfDs was greater than that for developmental effects (1,000 vs. 100), stemming from not applying a UF_S_ for the developmental effects. Application of the larger composite UF for liver and thyroid effects results in osRfDs that are fivefold lower than the developmental osRfD and thus protective of PFBA-induced effects on the developing organism. If the osRfD for developmental effects were chosen as the overall RfD on the basis of the application of a smaller composite UF, this would raise concerns that it would not be protective against potential liver and thyroid effects. Lastly, the selection of the overall RfD based on liver and thyroid effects is further supported by the fact that the confidence in that RfD is medium, compared with medium-low for developmental effects. Selection of the RfD based on liver and thyroid effects is presumed to be protective of possible developmental effects in humans, although uncertainty in the database currently available for PFBA remains including a lack of information on the potential for sensitive transgenerational, neurodevelopmental, or developmental immune effects of PFBA exposure (see discussion on UF_D_ selection above).

Increased liver hypertrophy and decreased total T4 was observed only in male rats exposed to PFBA, thus possibly identifying males as a susceptible population. As discussed in Section 3.3, however, this observation in rats could be driven primarily by the observed sex-dependent differences in pharmacokinetics in rats. No compelling information is available that supports a similarly strong sex dependence in pharmacokinetics in humans. Therefore, this RfD is presumed equally applicable to both male and female humans.

### 5.2.2 Subchronic Toxicity Values for Oral Exposure (Subchronic Oral Reference Dose [RfD]) Derivation

In addition to providing RfDs for lifetime exposures in multiple systems, this document also provides an RfD for less-than-lifetime, subchronic-duration exposures. In the case of PFBA, all studies used to calculate the RfDs were subchronic or gestational in duration. Therefore, the method to calculate the subchronic RfDs is identical to that used for calculating the RfDs, minus the application of a 10-fold UF_S_ for the subchronic studies (see Table 5-6). The individual organs and systems for which specific candidate subchronic RfD values were derived were the liver, thyroid, and the developing organism (see Table 5-10).

Table 5-10 Candidate subchronic oral reference dose (RfD) values for perfluorobutanoic acid (PFBA)

Endpoint | PODHED PFBA (mg/kg-d) | UF_A_ | UF_H_ | UF_S_ | UF_L_ | UF_D_ | UF_C_ | Candidate value PFBA (mg/kg-d) | Candidate value NH_4_^+^ PFB (mg/kg-d)^a^
Increased relative liver weight; Butenhoff et al. (2012a) | 2.04 | 3 | 10 | 1 | 1 | 3 | 100 | 2.0 × 10^−2^ | 2.2 × 10^−2^
Increased relative liver weight; Das et al. (2008) | 2.46 | 3 | 10 | 1 | 1 | 3 | 100 | 2.5 × 10^−2^ | 2.7 × 10^−2^
Increased liver hypertrophy; Butenhoff et al. (2012a) | 1.15 | 3 | 10 | 1 | 1 | 3 | 100 | 1.1 × 10^−2^ | 1.2 × 10^−2^
Decreased total T4; Butenhoff et al. (2012a) | 1.27 | 3 | 10 | 1 | 1 | 3 | 100 | 1.3 × 10^−2^ | 1.4 × 10^−2^
Embryo/fetal mortality; Das et al. (2008) | 0.93 | 3 | 10 | 1 | 1 | 3 | 100 | 9.3 × 10^−3^ | 1.0 × 10^−2^
Delayed eyes opening; Das et al. (2008) | 0.80 | 3 | 10 | 1 | 1 | 3 | 100 | 8.0 × 10^−3^ | 8.6 × 10^−3^
Delayed vaginal opening; Das et al. (2008) | 0.62 | 3 | 10 | 1 | 1 | 3 | 100 | 6.2 × 10^−3^ | 6.7 × 10^−3^

a To calculate subchronic candidate values, osRfDs, or the subchronic RfD for salts of PFBA, multiply the value of interest by the ratio of molecular weights of the free acid and the salt. For example, for the ammonium salt of PFBA, the RfD would be calculated by multiplying the free acid RfD by (M W a m m o n i u m s a l t)/(M W f r e e a c i d) = (231)/(214) = 1.079 . This same method of conversion can be applied to other salts of PFBA, such as the potassium or sodium salts, using the corresponding molecular weights.

From the identified human health hazards of PFBA exposure and the derived candidate RfDs, osRfDs of 1 × 10^−2^ mg/kg-day are selected for liver effects (increased liver hypertrophy) and thyroid effects (decreased total T4) (corresponding osRfD of 1 × 10^−2^ mg/kg-day for the ammonium salt), and an osRfD of 6 × 10^−3^ mg/kg-day PFBA is selected for developmental effects (developmental delays based on the candidate value for delayed vaginal opening) (corresponding osRfD of 7 × 10^−3^ mg/kg-day for the ammonium salt). The selection of these candidate values over other candidates and the confidence in these subchronic osRfDs are identical to the confidence in the osRfDs discussed in the previous section and presented in Table 5-8. Note, specifically for developmental delays, the candidate value for delayed eye opening was not selected as the osRfD as it was 33% larger than the candidate value for vaginal opening and thus inadequately protective of human health.

From these subchronic osRfDs, an overall subchronic RfD of 6 × 10^−3^ mg/kg-day PFBA based on developmental delays is selected (the corresponding overall subchronic RfD is 7 × 10^−3^ mg/kg-day for the ammonium salt). This osRfD is selected as the overall subchronic RfD, as it is the lowest osRfD among the derived subchronic osRfDs, even though it is not the osRfD interpreted with the highest confidence. In the case of the subchronic RfD, selection need not consider differences in the composite UF, as a value of 100 is applied to all PODs. This is because all the studies considered for the subchronic RfD are subchronic or gestational duration studies. This results in the osRfD for developmental delays being approximately 50% lower than the osRfD for liver or thyroid effects. Although the overall confidence in the osRfD for developmental delays (medium-low) is lower than for liver effects (medium confidence, see derivation of RfD section), selection of the developmental osRfD as the overall subchronic RfD is presumed protective of possible effects in other organ systems. Selection of the liver osRfD, although having a stronger overall confidence determination, as the overall subchronic RfD would be considered inadequate to protect against potential developmental effects. Also, although the subchronic RfD is intended to protect health during a less-than-lifetime exposure to PFBA, developmental delays are appropriate endpoints on which to base a subchronic RfD. First, as discussed above (Study Selection subsection), given delayed reproductive milestones occuring during critical periods of development, EPA’s Reproductive Toxicity Guidelines U.S. EPA (1996) state that significant effects on puberty (and thus by inference, the development of the male and female reproductive systems more broadly) “either early or delayed, should be considered adverse…”. Further, delays in reaching developmental milestones are not phenomena that can be resolved (e.g., after PFBA exposure is removed), and they can result from short (less-than-lifetime) exposures during discrete windows of development. More importantly, the consequences of these delays can have permanent impacts on health (e.g., delays in eye opening leading to permanent decrements in visual acuity). So, although the delay itself might occur only over a short portion of lifetime, the functional consequences are permanent.

### 5.2.3 Inhalation Reference Concentration (RfC)

No published studies investigating the effects of subchronic, chronic, or gestational exposure to PFBA in humans or animals have been identified. Therefore, an RfC is not derived.

## 5.3 CANCER

### 5.3.1 Cancer Weight-of-Evidence Descriptor and Derivation of Cancer Risk Values

No studies were identified that evaluated the carcinogenicity of PFBA in humans or animals. In accordance with the Guidelines for Carcinogen Risk Assessment U.S. EPA (2005), EPA concluded that there is inadequate information to assess carcinogenic potential for PFBA (or salts of PFBA) for any route of exposure. This conclusion precludes the derivation of quantitative estimates for either oral (oral slope factor [OSF]) or inhalation (inhalation unit risk [IUR]) exposure.

13 The systematic review protocol for PFBA (see Appendix A) defines perfluoroalkyl carboxylic acids with seven or more perfluorinated carbon groups and perfluoralkane sulfonic acids with six or more perfluorinated carbon groups as “long-chain” PFAS. Thus, PFHxA is considered a short-chain PFAS, whereas PFHxS is considered a long-chain PFAS.