# 4 SUMMARY OF HAZARD IDENTIFICATION CONCLUSIONS

## 4.1 SUMMARY OF CONCLUSIONS FOR NONCANCER HEALTH EFFECTS

The currently available evidence indicates hazards likely exist with respect to the potential for thyroid, liver, and developmental effects in humans, given relevant PFBA exposure conditions. These judgments are based on data from short-term (28-day exposure), subchronic (90-day exposure), and developmental (17-day gestational exposure) oral-exposure studies in rodents. Further characterizations of the exposure conditions relevant to the identified hazards are provided in Section 5. A summary of the justifications for the evidence integration judgments for each of the main hazard sections is provided below, organized by health effect, and further summarized in Table 4-1.

The hazard identification judgment that the evidence indicates PFBA exposure is likely to cause thyroid toxicity in humans (given relevant circumstances) is based primarily on a short-term and subchronic study in male rats reporting a consistent and coherent pattern of hormonal, organ weight, and histopathological changes, generally at PFBA exposure levels ≥30 mg/kg-day, although some notable effects were observed at 6 mg/kg-day. For effects on the thyroid in exposed animals, PFBA-induced perturbations were observed in one species and sex (male rats) across two different exposure durations (short-term and subchronic). Consistent, dose-dependent decreases in total and free T4 were observed independent of any effect on TSH. Additionally, increased thyroid weights and increases in thyroid follicular hypertrophy were observed. Although the observed thyroid histopathological changes support the potential for PFBA to disrupt the thyroid hormone homeostasis, however, rodents are uniquely sensitive to the development of thyroid follicular hypertrophy and tumor development U.S. EPA (1998b) compared with humans. Because of the similarities in the production and regulation of thyroid hormone homeostasis between rodents and humans and the consistency of the observed pattern of effects with changes observed in humans, the effects in rodents were considered relevant to humans. A detailed discussion of thyroid effects is included in Section 3.2.1.

The hazard identification judgment that the evidence indicates PFBA exposure is likely to cause hepatic toxicity in humans, given relevant exposure circumstances, is based primarily on a series of short-term, subchronic, and developmental studies in rats and mice, generally exhibiting effects at PFBA exposure levels ≥30 mg/kg-day. The PFBA-induced effects were observed in two species (rats and mice), in males and females, and across multiple exposure durations (short-term, subchronic, and gestational). Consistent, coherent, dose-dependent, and biologically plausible effects were observed for increased liver weights and increased incidences of hepatic histopathological lesions. Supporting the biological plausibility and human relevance of these effects is mechanistic information that suggests non-PPARα MOAs could explain some of the observed effects in exposed rodents and that observed effects might be precursors to clearly adverse health outcomes such as steatosis. Supporting this conclusion is evidence from other PFAS that have consistently shown that longer chain PFAS can activate non-PPARα nuclear receptors, including PPARγ, CAR, and PXR, although there is uncertainty in inferring a similar relationship for the short-chain PFBA.

The hazard identification judgment that the evidence indicates PFBA exposure is likely to cause developmental effects in humans (given relevant exposure circumstances), including increased prenatal effects (full-litter resorptions) and delays in developmental milestones (days to eye opening, vaginal opening, and preputial separation) without effects on fetal (pup) growth is based on a single study in mice exposed gestationally to PFBA. Although the observed developmental effects due to PFBA exposure were investigated in only one high confidence study, they demonstrate a constellation of effects affecting the developing organism that is internally coherent (within-study) and consistent across related PFAS compounds, including PFBS, PFOA, and PFOS.

There was inadequate evidence to determine whether PFBA exposure has the potential to cause reproductive toxicity (in adults), effects on hematological or clinical chemistry markers, ocular effects, changes in blood pressure, or effects on renal function in humans. Other potential health outcomes have not been evaluated in the context of PFBA exposure. Most notably, potential for PFBA exposure to affect the immune system, thyroid or nervous system in developing organisms, or mammary glands represent important data gaps given the associations observed for other PFAS, such as PFBS, PFOA, PFOS, and GenX (U.S. EPA, 2021a; MDH, 2020, 2019, 2018; U.S. EPA, 2018b, 2016a, b). See Table 4-2 for a comparison of the noncancer hazard judgments drawn for PFBA with the judgments in the final EPA assessments for PFBS, PFOA, PFOS, and GenX.

Table 4-1 Evidence integration summary for health effects for which evidence indicates a hazard exists

Evidence stream scenarios | | Evidence in studies of humans^a^ | Evidence in animal studies^a^ | Evidence basis
Arrow - Stronger evidence stream scenarios | No Studies, or Low Confidence or Conflicting Evidence | Developmental; Hepatic; Thyroid | | Developmental; - No human studies; - Coherent observations of delays in developmental milestones (eye opening, vaginal opening, preputial separation) and fetal mortality in one high confidence study of mice exposed gestationally; - Consistent with findings for related PFAS; - No MOA information; - Human relevance presumed; Thyroid; - Single low confidence study in humans; - Consistent and biologically coherent results for thyroid hormone levels (T4 without compensatory changes in TSH), organ weights, and histopathology from two high confidence studies (short-term, subchronic) in male rats; - Consistent with findings for related PFAS; - No MOA information; - Human relevance presumed; Hepatic; - Two null studies (one medium and one low confidence) in humans with poor sensitivity; - Consistent, dose-dependent, and biologically coherent effects on liver weights and histopathology from seven high or medium confidence studies in adult male rats and mice (short-term and subchronic) and adult and female mice exposed as adults or gestationally; - PPARα-dependence observed for some effects (focal necrosis) but other effects (vacuolation) occur in animals lacking PPARα activity (null mice) or in animals with human PPARα (humanized mice); - Involvement of both PPARα-dependent and independent mechanisms, including hypertrophic responses in humanized PPARα mice; - MOA information supports human relevance
Arrow - Stronger evidence stream scenarios | Strong Mechanistic Evidence Alone
Arrow - Stronger evidence stream scenarios | One High or Medium Confidence Apical Study without Supporting or Conflicting Evidence | | Developmental
Arrow - Stronger evidence stream scenarios | Multiple High or Medium Confidence Apical Studies with Some Inconsistency or Important Uncertainties | | Thyroid; Hepatic
Arrow - Stronger evidence stream scenarios | Multiple High or Medium Confidence Apical Studies with Strong Support (e.g., MOA understanding supporting biological plausibility)

a Can include consideration of studies informing biological plausibility: For studies in humans, this includes studies of human tissues or cells, and other relevant simulations; for animal studies, this includes ex vivo and in vivo experiments and other relevant simulations.

Table 4-2 Hazard conclusions across published EPA PFAS human health assessments

Health Outcome | EPA PFAS Assessments^a,b,c^
Health Outcome | PFBA | PFBS | GenX Chemicals | PFOA^d^ | PFOS^d^
Thyroid | + | + | −^e^ | Human: +; Animal: +/− | Human: +/−; Animal: +/−
Liver | + | − | + | Human: +; Animal: + | Human: −; Animal: +
Developmental | + | + | +/− | Human: +; Animal: + | Human: +; Animal: +
Reproductive | − | − | +/− | Human: −; Animal: +/− | −^e^
Immunotoxicity | − | − | +/− | Human: +; Animal: + | Human: +/−; Animal: +
Renal | − | + | +/− | Human: +/−; Animal: +/− | −^e^
Hematological | − | −^e^ | +/− | −^e^ | −^e^
Ocular | − | −^e^ | −^e^ | −^e^ | −^e^
Serum Lipids | −^e^ | − | −^e^ | Human: +; Animal: + | Human: +
Hyperglycemia | −^e^ | −^e^ | −^e^ | Human: −; Animal: − | Animal: +/−
Nervous System | −^e^ | −^e^ | −^e^ | Human: −; Animal: − | Animal: +/−
Cardiovascular | −^e^ | − | −^e^ | −^e^ | −^e^
Cancer | − | − | +/− | +/− | +/−

a Assessments used multiple approaches to summarizing their non-cancer hazard conclusions; for comparison purposes, the conclusions are presented as follows: ‘+’ =evidence demonstrates or evidence indicates (e.g., PFBA), or evidence supports (e.g., PFBS); ‘+/−’ =suggestive evidence; ‘−’ = inadequate evidence (e.g., PFBA) or equivocal evidence (e.g., PFBS); and ‘−/−’ = sufficient evidence to conclude no hazard (no assessment drew this conclusion).

b The assessments all followed the EPA carcinogenicity guidelines (2005) U.S. EPA (2005) a similar presentation to that used to summarize the noncancer judgments is applied for the cancer hazard conclusions, as follows: ‘+’ = carcinogenic to humans or likely to be carcinogenic to humans; ‘+/−’ = suggestive evidence of carcinogenic potential; ‘’ = inadequate information to assess carcinogenic potential; and ‘−/−’ = not likely to be carcinogenic to humans (no assessment drew this conclusion).

c The hazard conclusions for the various EPA PFAS assessments presented in this table were not considered during evidence integration and thus did not inform the evidence integration conclusions presented in the PFBA assessment.

d The U.S. EPA PFOA U.S. EPA (2016b) and PFOS U.S. EPA (2016a) assessments did not use structured language to summarize the noncancer hazard conclusions. The presentation in in this table was inferred from the hazard summaries found in the respective assessments; however, this is for comparison purposes only and should not be taken as representative of the conclusions from these assessments. Those interested in the specific noncancer hazard conclusions for PFOA and PFOS must consult the source assessments. Note that new assessments for PFOA and PFOS are currently being finalized to support a National Primary Drinking Water Regulation; hazard conclusions in these updated assessments may differ from those presented in this table.

e No data available for this outcome for this PFAS, so ‘− ‘entered by default.

## 4.2 SUMMARY OF CONCLUSIONS FOR CARCINOGENICITY

No human or animal studies were available to inform the potential for PFBA exposure to cause cancer and the single study of genotoxicity did not observe effects. Overall, there is inadequate information to assess the carcinogenic potential of PFBA exposure. See Table 4-2 for a comparison of the carcinogenicity conclusion drawn for PFBA with the carcinogenicity conclusions in the final EPA assessments for PFBS, PFOA, PFOS, and GenX.

## 4.3 CONCLUSIONS REGARDING SUSCEPTIBLE POPULATIONS AND LIFESTAGES

No human studies were available to inform the potential for PFBA exposure to affect sensitive subpopulations or lifestages.

In adult animals exposed subchronically, PFBA exposure was consistently observed to elicit stronger responses in male rats compared with female rats. The reason for this sex dependence is most likely due to differences in pharmacokinetics between males and females. The serum half-life of PFBA following a single oral dose of 30 mg/kg-day is approximately 9 hours in male rats, compared to 2 hours in female rats (see Table 3-2). Differences in half-life values is similar in mice, with male mice having much longer half-lives than females at 30 mg/kg-day (16 hours vs. 3 hours). Urinary excretion rates are much faster in female rodents compared to male rodents (approximately 50%–90% faster), possibly due to renal reabsorption of PFBA in male rats by organic anion transporters (OATs). However, as noted in Section 3.1.4, PFBA is not an active substrate of OAT1, OAT2, or OATP1a1 which are expressed in the kidney and active towards other PFAS, and as described at the end of Section 3.1.5, it seems unlikely that urinary excretion of albumin (which is not sex-dependent in control rats (Matsuzaki et al., 2002)) could explain the observation.

Further, and specifically relevant to hepatic effects, the liver concentrations of PFBA following subchronic exposure to 30 mg/kg-day is approximately 16-fold higher in male rats than in female rats [16.09 vs. 0.91 mg/kg-day; Butenhoff et al. (2012a); van Otterdijk (2007a, 2007b)], and responses for liver weight are 11-fold higher (33% vs 3% increase, see Table 3-6). 0.91 mg/kg-day; Butenhoff et al. (2012a); van Otterdijk (2007a, 2007b)], and responses for liver weight are 11-fold higher (33% vs 3% increase, see Table 3-6). On the other hand, the estimated clearance in male rats is only 4.5-fold lower than in female rats (see Table 3-2). Thus, PFBA clearance (primarily in the urine) partly explains the sex difference in internal dose and liver weight effect, suggesting that additional sex-related differences that impact the distribution to the liver contribute to the overall difference in response for this endpoint. However, reductions in free and total T4 at 150 mg/kg-day after 28 days and at 30 mg/kg-day after 90 days were 2- to 3-fold less severe in female rats compared to male rats (see Table 3-3), which is somewhat less than the relative clearance (4.5-fold), but sufficiently similar to suggest that the difference in clearance is a primary factor in the difference in response.

No difference in serum half-lives was observed in monkeys exposed to a single i.v. dose of 10 mg/kg: 1.61 hours for males vs. 2.28 hours in females (Chang et al., 2008). Also, although quantitative data were not provided, serum excretion half-lives were reported not to differ between males and females in the one occupational study available (Chang et al., 2008). Additionally, effects on liver weight were observed in pregnant and nonpregnant mice (Das et al., 2008). Developmental effects also were observed in female fetuses/neonates (full litter resorption, delayed eye opening, delayed vaginal opening) and male fetuses/neonates [full litter resorption, delayed eye opening, delayed preputial separation; Das et al. (2008)], with no clear difference in sensitivity. Therefore, although there does appear to be a clear sex dependence for some PFBA-induced health effects in adult rodents, the observed lack of sex-specific sensitivity for other effects in adult and immature rodents and the apparent lack of pharmacokinetic differences between sexes in primates (and a single human occupational study) preclude the identification of males as a broadly sensitive subpopulation for PFBA-induced health effects in humans.

Lastly, given the effects observed in pregnant mice (increased liver weights, full-litter resorptions) and the developing organism (fetal/postnatal death and delays in time to eye opening, vaginal opening, and preputial separation), that pregnancy and early life represent two sensitive lifestages to PFBA exposure is possible.