# 3 PHARMACOKINETICS, EVIDENCE SYNTHESIS, AND EVIDENCE INTEGRATION

## 3.1 PHARMACOKINETICS

Pharmacokinetic studies have been conducted with dosing solutions prepared from PFBA [e.g., (Burkemper et al., 2017)] and the ammonium and potassium salts [e.g., (Chang et al., 2008)]. Some of the results evaluated below are semi-qualitative (e.g., that distribution is to all tissues of the body), hence are described with reference to the acidic form, since given PFBA’s pKa of 0.08 the salts immediately dissociate after dissolution and analytic measurements are of the perfluorobutanoate ion. These results are applicable independent of the form used to prepare dosing solutions.

The one study for which quantitation of the pharmacokinetic parameters might depend on the form is (Chang et al., 2008). Chang et al. (2008) was careful to identify the form used for each part of their study so it is also clear that the chemical analysis used to measure concentrations in serum used to determine pharmacokinetic parameters is that of the acid, PFBA. However, calculation of the volume of distribution and clearance also involves the administered dose and Chang et al. (2008) does not specify whether or not the doses were converted to dose of the acid form. In a subsequent paper by the same research group evaluating the pharmacokinetics of PFHxS, Sundström et al. (2012) explicitly state, “concentrations in serum, liver, urine and feces are reported as PFHxS anion, and percent recoveries of administered dose in those matrices are corrected for the potassium salt.” Hence, we will presume that Chang et al. (2018) similarly corrected either the applied dose or the serum concentrations to consistent units before reporting their pharmacokinetic parameters. Since the key parameters, volume of distribution and clearance, effectively involve the ratio of dose to serum concentration (or the area-under-the-concentration curve), resulting in measures of volume per kg BW or volume per time that are independent of the molecular weight, these results can be applied to analysis of PFBA per se, i.e., the acid or anion. Conversion to corresponding doses of a given salt is applied before or after pharmacokinetic analysis then provides the appropriate human equivalent doses for each form.

Animal evidence has shown that PFBA, like other perfluorinated chemicals, is well absorbed following oral administration and distributes to all tissues examined (Burkemper et al., 2017). A study evaluating the volume of distribution concluded, however, that the empirical volume of distribution is in the range typically associated with extracellular distribution (Chang et al., 2008). Because of its chemical resistance to metabolic degradation, PFBA appears to be primarily eliminated unchanged in urine and feces.

Pharmacokinetic studies of PFBA in rats, mice, and monkeys have been performed, providing information on the absorption, distribution, metabolism, and excretion (ADME) of PFBA (Burkemper et al., 2017; Chang et al., 2008). Also, Russell et al. (2015a) evaluated the metabolism of 6:2 fluorotelomer alcohol (6:2 FTOH) in mouse, rat, and human hepatocytes, showing that PFBA is a metabolite of 6:2 FTOH, and evaluated PFBA pharmacokinetics (PK) after inhalation and oral exposure of rats to 6:2 FTOH. The distribution of PFBA in human tissues also has been investigated (Pérez et al., 2013). Information on the absorption and distribution of PFBA to the serum and liver specifically has been investigated in several toxicological studies (Gomis et al., 2018; Butenhoff et al., 2012a; Foreman et al., 2009; Das et al., 2008).

### 3.1.1 Absorption

Chang et al. (2008) conducted a set of pharmacokinetic experiments in which Sprague-Dawley (S-D) rats three male and three female) were given either a single intravenous (i.v.) or oral dose (30 mg/kg body weight via gavage) of ammonium perfluorobutanoate (NH_4_^+^PFB). The serum area-under-the-concentration-curve (AUC) was 1,090 ± 78 and 239 ± 5 (µg-h/mL) in male and female rats, respectively, after i.v. dosing and 1,911 ± 114 and 443 ± 42 in males and females, respectively, after oral dosing. That the AUC after oral dosing was almost two times higher than after i.v. dosing is theoretically impossible but might be a statistical result from the small sample size (n = 3/group) or due to a problem in dosing. The result, however, indicates 100% oral absorption.

In other experiments, Chang et al. (2008) orally administered 3−300 mg/kg to male and female S-D rats via gavage. As expected, the concentration of PFBA in the serum increased with dose in a fairly linear fashion up to 100 mg/kg PFBA; however, the serum concentration of PFBA in rats dosed orally to 300 mg was approximately 60% the concentration at 100 mg/kg. Maximum concentration (C_max_) values were similar in males and females following oral exposures to 30 mg/kg PFBA (131 ± 5 and 136 ± 12 µg/mL, respectively), but the time to peak concentration (T_max_) differed between sexes: 1.25 ± 0.12 hours for males and 0.63 ± 0.23 hours for females. Both values, however, indicate that absorption to the serum was fairly rapid in rats.

C_max_ values for male and female mice exposed to PFBA via oral gavage also were similar at lower doses (10 mg/kg; 50.50 ± 5.81 and 52.86 ± 2.08 µg/mL) but differed at 30 mg/kg (119.46 ± 13.86 and 151.20 ± 6.92 µg/mL) and 100 mg/kg (278.08 ± 20.38 and 187.97 ± 15.90 µg/mL). C_max_ and T_max_ values for rats and mice at 30 mg/kg appear similar; however, the T_max_ was higher in female mice than in male mice (the opposite relationship compared to rats).

### 3.1.2 Distribution

Burkemper et al. (2017) investigated the distribution of PFBA in male CD-1 mice (n = 4) given a single i.v. dose of radiolabeled ^[1^8F]-PFBA (~0.074 MBq/μL). At 4 hours postinjection, the ^[1^8F]-PFBA was detected in every tissue investigated, with most of the dose found in the stomach (~7.5% injected dose/g). All concentrations in the blood, lung, liver, kidney, intestines, and skin were similar (~2%–3%). Compared with perfluorooctanoic acid (PFOA) and perfluorohexanoic acid (PFHxA), the concentration of PFBA was much lower in the liver (~27% and ~20%, respectively). Chang et al. (2008) estimated volumes of distribution (V_d_, mL/kg) for NH_4_^+^PFB in male and female rats (209 ± 10 and 173 ± 21 at 30 mg/kg orally), mice (152 and 107 at 10 mg/kg orally; 296 and 134 at 30 mg/kg orally), and cynomolgus monkeys (526 ± 68 and 443 ± 59 at 10 mg/kg i.v.) (N = 3 animals/sex/dose group for all species); these values indicate that NH_4_^+^PFB is primarily distributed in the extracellular space.

Distribution in rats and mice was also examined in multiple toxicological studies of PFBA (see Table 3-1). Although limited in scope (i.e., PFBA was measured only in the liver and blood serum), these studies demonstrated consistently that PFBA does distribute to the liver compartment in both species. Butenhoff et al. (2012a) observed that liver concentrations of PFBA (µg/g) were higher in male and female S-D rats exposed to PFBA for 28 days vs. rats exposed for 90 days. The ratio between liver concentrations (µg/g) and serum concentrations (µg/mL) ranged from 26% to 47% in the 28-day rats and 16% to 31% in the 90-day rats. In both exposure groups, the concentration of PFBA in the serum or liver was drastically reduced following a 3-week recovery period.

Das et al. (2008) investigated the distribution of PFBA to the liver in both pregnant and nonpregnant mice and in postnatal day (PND) 1 and PND 10 pups. Serum levels and liver levels of PFBA appeared to be lower in nonpregnant mice compared to pregnant mice in the lowest two dose groups, with mean serum concentrations approximately twofold higher in pregnant mice compared to nonpregnant mice in the 35 mg/kg-day and 175 mg/kg-day dose groups (see Table 3-1). This pattern also was observed for liver concentrations where pregnant animals had approximately two to three times the liver concentration of PFBA compared to nonpregnant animals in the 35 mg/kg-day and 175 mg/kg-day dose groups. However, these differences were not statistically significant and are based on only two or three nonpregnant mice at each dose level, and serum and liver levels were essentially identical between pregnant and nonpregnant mice at the high dose (350 mg/kg) level. Additionally, the serum and liver concentrations of PFBA were attenuated in high-dose (350 mg/kg) animals. Possible explanations for this pattern (with both liver and serum levels being lower in non-pregnant than pregnant animals) would be higher oral absorption, lower clearance, or higher distribution to other tissues (including fetuses and placenta) at the intermediate doses but not at the higher doses in the pregnant mice. However, serum concentrations in PND 1 pups were about 7-fold lower than the pregnant dams (end of gestation) and liver concentrations were 6−7 fold lower, indicating that distribution to the fetuses was not higher than distribution to other maternal tissues. Since PFBA absorption data (see Section 3.1.1) are consistent with close to 100% absorption, similar to other PFAS, it is not possible for absorption to be increased during pregnancy. It is possible that clearance is reduced during pregnancy due to hormonal changes affecting renal transporters, increasing resorption and hence internal doses, with this effect being neutralized by saturation of the transporters at the highest doses. Pharmacokinetic data from Chang et al. (2008) (see Section 3.1.4) are consistent with saturation of renal resorption in the range of 3-100 mg/kg doses in female mice, which supports this possible explanation. However, given the small sample-size of the non-pregnant animals in Das et al. (2008) and the fact that the animals were dosed for 17 days, compared to the single doses used in PK studies, additional experiments would be needed to validate and more accurately quantify any pregnancy-related differences.

As would be expected, both the serum and liver concentrations in PND 1 pups were much greater than those in PND 10 pups, since dosing ceased on GD 18 (Das et al., 2008). Das et al. (2008) corroborated the observations by Butenhoff et al. (2012a) and Chang et al. (2008) that serum PFBA concentrations are higher than liver concentrations. The ratios of liver to serum PFBA concentration observed in Chang et al. (2008) were 22%−27% in male rats, 20%−23% in male mice, and 15%−17% in female mice. Interestingly, minimal differences in liver/serum concentrations also were observed in various genetic strains of mice exposed to 35−350 mg/kg PFBA: 34%–47% in wild-type mice, 19%–37% in peroxisome proliferator-activated receptor alpha (PPARα) null mice, and 22%–37% in humanized PPARα mice (Foreman et al., 2009). These results suggest that PPARα status has minimal effect on the distribution of PFBA between liver and serum.

Table 3-1 Serum and liver concentrations of perfluorobutanoic acid (PFBA) following subchronic or gestational exposure

Dose group (mg/kg-d) | Serum (μg/mL) | Liver (μg/g) | Serum (μg/mL) | Liver (μg/g)
Dose group (mg/kg-d) | Pregnant mice Das et al. (2008) | | Nonpregnant female mice Das et al. (2008)
0 | 0.002 ± 0.001 | 0.003 ± 0.002 | 0.006 ± 0.003 | 0.038 ± 0.017
35 | 3.78 ± 1.01 | 1.41 ± 0.42 | 1.96 ± 1.0 | 0.51 ± 0.20
175 | 4.44 ± 0.65 | 1.60 ± 0.25 | 2.41 ± 1.65 | 0.86 ± 0.55
350 | 2.49 ± 0.60 | 0.96 ± 0.18 | 2.67 ± 1.2 | 0.89 ± 0.38
| PD1 male and female mice Das et al. (2008) | | PD10 male and female mice Das et al. (2008)
0 | Not detected | 0.004 ± 0.001 | 0.002 ± 0.002 | 0.003 ± 0.001
35 | 0.56 ± 0.15 | 0.22 ± 0.05 | 0.11 ± 0.03 | 0.04 ± 0.01
175 | 0.61 ± 0.39 | 0.29 ± 0.14 | 0.14 ± 0.07 | 0.04 ± 0.02
350 | 0.37 ± 0.14 | 0.24 ± 0.08 | 0.12 ± 0.05 | 0.04 ± 0.02
| 28-d male rats Butenhoff et al. (2012a) | | 90-d male rats Butenhoff et al. (2012a)
0 | 0.04 ± 0.05 | <0.05 | <0.01 | <0.05
1.2 | – | – | 6.10 ± 5.22 | 1.34 ± 1.24
6 | 24.65 ± 17.63 | 7.49 ± 4.46 | 13.63 ± 9.12 | 3.07 ± 2.03
30 | 38.04 ± 23.15 | 17.42 ± 8.15 | 52.22 ± 24.89 | 16.09 ± 9.06
150 | 82.20 ± 31.83 | 37.44 ± 18.12 | – | –
| 28-d female rats Butenhoff et al. (2012a) | | 90-d female rats Butenhoff et al. (2012a)
0 | 0.01 ± 0.01 | 0.05 ± 0.03 | 0.07 ± 0.06 | <0.05
1.2 | – | – | 0.23 ± 0.14 | 0.05 ± 0.02
6 | 0.34 ± 0.13 | 0.16 ± 0.04 | 0.92 ± 0.52 | 0.15 ± 0.08
30 | 1.72 ± 0.88 | 0.434 ± 0.174 | 5.15 ± 3.29 | 0.91 ± 0.55
150 | 10.30 ± 4.50 | 2.70 ± 1.47 | – | –
| 28-d PPARα +/+ mice Foreman et al. (2009)^*^ | | 28-d PPARα −/− mice Foreman et al. (2009)^*^
35 | 87 ± 27 | 30 ± 1.6 | 67 ± 14 | 13 ± 1
175 | 108 ± 7 | 51 ± 5 | 99 ± 16 | 36 ± 7
350 | 115 ± 11 | 46 ± 4 | 81 ± 20 | 28 ± 5
| 28-d hPPARα mice Foreman et al. (2009)^*^
35 | 59 ± 12 | 21 ± 4
175 | 146 ± 20 | 32 ± 4
350 | 35 ± 5 | 9 ± 2

a Foreman et al. (2009) analyzed tissue concentrations in male wild-type (PPARα +/+), PPARα −/− and humanized PPARα (hPPARα) mice on an Sv/129 genetic background. * Foreman et al. (2009) analyzed tissue concentrations in male wild-type (PPARα +/+), PPARα −/− and humanized PPARα (hPPARα) mice on an Sv/129 genetic background.

Pérez et al. (2013) investigated the distribution of PFBA in multiple tissues in cadavers in Tarragona County, Spain. PFBA was detected in liver, brain, lung, and kidney samples, but was below the level of detection in bone. Lung and kidney samples by far had higher PFBA concentrations (304 and 464 ng/g, respectively) than brain or liver samples (14 and 13 ng/g, respectively). For both the lungs and kidneys, PFBA was detected in greater quantities than any of the other 20 per- and polyfluoroalkyl substances (PFAS) analyzed. The observation that PFBA was observed in the greatest quantities in kidney samples could be related to kidney reabsorption. Chang et al. (2008) observed that rats given 300 mg/kg PFBA orally excreted substantially greater amounts of PFBA in the urine than did rats given 100 mg/kg (90.16% ± 2.75% vs. 50.99% ± 4.35%), and the authors suggested this as evidence of saturation of a renal tubular reabsorption process.

Abraham et al. (2021) analyzed PFBA levels in lung and tissue samples collected from tumor patients in France and observed concentrations approximately three to four orders of magnitude lower than Pérez et al. (2013): 0.08–0.24 ng/g in lung (n = 7) and 0.04−0.19 ng/g in kidney (n = 9). These were different individuals living in a different country, so some difference in exposure levels is expected. Additionally, tissue samples were obtained from cancer patients versus people that died from trauma or ischemic heart disease, further complicating the comparison. But given the relatively rapid clearance of PFBA compared to other PFAS, one would expect its tissue levels to be lower than other PFAS, not the highest, and one would have to assume that exposure to the subjects of Abraham et al. (2021) to be thousands of times lower than the subjects of Pérez et al. (2013) order to otherwise explain the difference. Bangma et al. (2021) determined that a saturated oxo-fatty acid as an analytic interferent with PFBA in the placenta, indicating that it could also have given falsely high measurements in the Pérez et al. (2013) lung samples. It is noted that Pérez et al. (2013) describe careful and fairly comprehensive quality-assurance (QA) methods employed, such as use of matrix-matched calibration, while Abraham et al. (2021) does not report what QA/quality-control (QC) methods were used. Given the QA of (Pérez et al., 2013) an interferent would need to be present in human lung but not pig lung (species source of tissues used for QA) to result in large over-estimates. Resolution of this discrepancy is beyond the scope of this review and likely requires additional tissue samples from a larger population, preferably one with known PFBA exposure levels in the weeks immediately prior to sampling, given the short half-life.

Data are not available that can be used reliably to estimate the volume of distribution (V_d_) in humans, which effectively provides the total body burden based on observed blood or serum concentrations. An estimation of human body distribution for other PFAS is provided by the PBPK models for PFOA and PFOS of Loccisano et al. (2011) which assume identical tissue:blood partition coefficients (PCs) in humans and monkeys, equal to the values measured using tissues from rats (PFOA) and mice (PFOS). This assumption is common to many PBPK models, based on the expectation that the biochemical properties of a given tissue, muscle for example, which determines the relative affinity of a chemical for that tissue compared to blood, are similar across mammalian species: mouse, rat, monkey, and human muscle are all similar in composition and the difference in chemical distribution to muscle as a whole is determined by the difference in the volume of muscle per kg BW between species.

PCs are the effective tissue specific V_d_ values because they determine the ratio of the amount in a tissue vs. blood concentration at equilibrium. Based on this PBPK model Loccisano et al. (2011), the V_d_ for PFOA predicted in monkeys and humans is 0.210 and 0.195 L/kg, respectively, and for PFOS is 0.333 and 0.322 L/kg, respectively. These predictions are obtained by summing the tissue fractions (ratios of tissue volumes/BW) multiplied by the corresponding PCs. In comparison, based on the Loccisano et al. (2011) model for adult rats, the corresponding V_d_ values in that species, for PFOA and PFOS, are 0.290 and 0.398, respectively. The difference between these rat values and the human and monkey values is primarily due to the difference in physiology, specifically the proportion of BW that is liver, kidney, and other tissues. Because of the physiological similarities between humans and monkeys (more similar tissue fractions), the predicted V_d_ values are within 7% of each other, although the difference between human and rat V_d_ values is predicted to be 49% for PFOA and 24% for PFOS. They are much more similar between humans and monkeys than between humans and rats, but the difference between humans and rats is still less than a factor of 1.5.

Li et al. (2020) evaluated the transplacental transfer of multiple PFAS, including PFBA, in human preterm vs. full-term births, and evaluated the data for correlation with the expression of nine placental transporters. The transplacental transfer efficiency (TTE) was calculated as the ratio of PFAS concentration in cord serum, collected at the time of birth, to the concentration in maternal serum collected within 1 week of (prior to) birth. The median TTE for preterm births was 0.48, with first and third quartiles of Q1 = 0.27 and Q3 =1.06 (n = 33) Li et al. (2020), hence the distribution in the preterm fetus was predominantly less than one though it may not be significantly so. This result is qualitatively consistent with the observations of Das et al. (2008) in mice, described above. However, the human TTE was observed to increase to a median value of 1.06 in full-term deliveries, with the difference between preterm and full-term indicated as significant (Li et al., 2020). This result is consistent with a possible loss of integrity of the placenta as a passive barrier to PFAS transport occurring towards the end of pregnancy, as discussed by the authors, since the TTE did not show a significant correlation with any of the transporters evaluated (Li et al., 2020).

The extent to which the volume of distribution may change during pregnancy in humans has not been evaluated. Based on data reported by Kuczmarski et al. (2000) an average woman gains about 25% of her initial body-weight during pregnancy. If the data of Li et al. (2020) can be interpreted as showing that distribution to this additional mass is about one half of distribution to other maternal tissues, then the total volume of distribution in the pregnant mother (L) would increase about 12.5% while her mass increases 25%, leading to V_d_ in late pregnancy of 112.5/125 = 90% of non-pregnant V_d_, which is not a significant change. Even if distribution to the fetus was much lower in the human fetus than the mother, her V_d_ would decrease by no more than 20%. While such a change may be marginally significant, it is still well within the overall uncertainty for estimates of V_d_. Another factor during human pregnancy is the decrease in serum proteins, with the decrease in albumin concentration being consistent with dilution of the protein into an increased total plasma volume (Paaby, 1960). Such a decrease could lead to both an increased V_d_ of PFBA, since a smaller fraction would be bound in blood, and an increase in clearance. Since the reduction in protein concentration is on the order of 10%−20% (Paaby, 1960) like the potential change due to the growth of the fetus discussed just above, the impact is not expected to be large, and it is in the opposite direction of that effect. Hence, while pregnancy-related factors specific to distribution may cause some change in distribution, this change is not expected to be significant. On the other hand, if hormonal changes increase renal resorption during pregnancy, as is suggested in mice (discussion above), that could significantly increase maternal body burden during that time. Measurements of clearance in pregnant vs. non-pregnant women (i.e., using matched blood and urine samples) would be needed to determine if such a difference exists.

Based on this analysis for PFOA and PFOS, the most reasonable choice for estimation of V_d_ for PFBA in humans is to assume that it is similar to the V_d_ estimated for PFBA in monkeys, rather than values estimated for mice or rats.

It is recognized that the distribution of PFAS depends on the extent of binding to various proteins and partitioning into phospholipid membranes. Chen and Guo (2009) measured the binding of PFBA to human serum albumin and obtained a binding constant of (1.1 ± 0.1) × 10^6^ M^-1^ for albumin site I with no observed binding to the Trp site or site II. However, corresponding measures of phospholipid partitioning and binding to cellular proteins are not available, so it is not possible to estimate the extent to which these contribute to tissue partitioning.

### 3.1.3 Metabolism

PFBA has been shown to be a product of the metabolism of 6:2 FTOH in mice, rats, and humans (Russell et al., 2015b; Ruan et al., 2014). No evidence of biotransformation for PFBA, however, was found. PFBA, a short-chain (C4) of perfluoroalkyl acids (PFAAs), is expected to be metabolically inert because its chemical stability is the same as longer chain PFAA chemicals, including perfluorohexane sulfonate (PFHxS, C6), perfluorooctane sulfonate (PFOS, C8), and PFOA, C8.

### 3.1.4 Excretion

In an overview of the toxicology of perfluorinated compounds, Lau (2015) briefly summarized the excretion half-lives of seven compounds, including PFBA. All supporting data for that review pertinent to PFBA are included in this analysis.

Chang et al. (2008) investigated the excretion of PFBA in S-D rats, CD-1 mice, cynomolgus monkeys, and workers occupationally exposed to PFBA, or compounds metabolized to PFBA. For rats and monkeys, three animals per sex were used (rats: three animals each for i.v. and oral dosing) at the single dose given to each. For mice, three animals per sex per time point were used at each dose, or 15–18 animals/dose. OECD guidelines state that a minimum of four animals per sex per dose should be used (OECD, 2010). Thus, the rat and monkey studies fall short of this standard. For rats, however, the average clearance from the two routes of exposure is proposed to best represent males and females of that species (details below), which is then based on data from six animals per sex. For monkeys, the average volume of distribution for both males and females are used as an estimate for that value in humans, again incorporating data from six animals. Therefore, these data are presumed sufficient for the specific parameters being estimated. In S-D rats exposed orally to 30 mg/kg PFBA, a marked difference was noted in the serum PFBA excretion constants (λ) between males and females, 0.075/hour and 0.393/hour, respectively, for oral exposure and 0.109/hour and 0.673/hour, respectively, for intravenous exposure (see Appendix C for a complete discussion on whether the calculated elimination constants in various species are mono- or biphasic). The difference in oral λ resulted in half-lives (t_1/2_) of 9.22 and 1.76 hours, respectively, for males and females. Chang et al. (2008) reported clearance (CL) values as mL/hour, not normalized to BW, but the normalized average CL can be calculated as dose/AUC, using the AUC values they reported. For oral doses in male and female rats, the result CLs are 0.38 and 1.6 L/kg-day, respectively, while for i.v. doses they are 0.66 and 3.0 L/kg-day, respectively.

Russell et al. (2015b) attempted to evaluate the excretion of PFBA, formed as a metabolite of 6:2 FTOH, after inhalation exposures in rats (strain not stated). In single-day studies, the animals were exposed by inhalation for 6 hours and their blood levels monitored for 24 hours after start of exposure. The decline in PFBA blood concentration was negligible, however, after 0.5 and 5 ppm 6:2 FTOH exposures in male rats and after 0.5 ppm exposure in female rats, precluding estimation of half-life. An excretion half-life of 19 hours was estimated from the 5-ppm single-day data for 5 ppm in female rats. After a 23-day inhalation exposure to male rats, use of a PK model resulted in estimation of a 27.7-hour half-life for that sex, which could explain the inability to estimate a half-life from the single-day exposures. Both estimates depend on the estimated yield (percent of 6:2 FTOH metabolized to PFBA), however, which was 0.2% for male rats and 0.02% for female rats. Given the low yields, small errors in the estimate of that parameter could result in significant errors in the estimated half-life. Thus, the results of Chang et al. (2008) is used to represent excretion in rats.

In male CD-1 mice, the clearance was similar in mice exposed to 10 mg/kg (0.35 ± 0.09 mL/hour) and 30 mg/kg PFBA (0.37 ± 0.80 mL/hour); however, clearance at 100 mg/kg was much higher (0.98 ± 0.14 mL/hour) (Chang et al., 2008). Although the fit of the simple one-compartment model used to describe the kinetic data appeared adequate for the two lower doses, it underpredicted the data at 24 and 48 hours for the 100 mg/kg dose, indicating it was not sufficient for this highest exposure. In female mice clearance showed a similar, but less strong pattern, with values of 0.76 ± 0.03, 0.87 ± 0.04, and 1.67 ± 0.08 mL/hour at 10, 30 and 100 mg/kg doses, respectively (Chang et al., 2008). Unlike the data for male mice, the female mouse data were fit well by the one-compartment PK model. For female data, the possible dose-dependence can be resolved by using the average clearance for the lower two doses, which are closer to the doses evaluated for point-of-departure (POD) determination. Because male mouse endpoints are not considered for POD determination, an alternative PK analysis of these data is not supported.

Using dose/AUC, the corresponding CL values are 0.23, 0.25, and 0.66 L/kg-day in male mice at 10, 30, and 100 mg/kg, respectively, and 0.62, 0.72, and 1.36 L/kg-day in female mice, respectively.

Cynomolgus monkeys (N = 3/sex) displayed a clear biphasic excretion pattern, with a rapid decline in the initial (α) phase and a slower decline in the second (β) phase (Chang et al., 2008). Notably, the β phase began at around 24 hours and was observed because samples also were taken at 2, 4, 7, and 10 days, while in rodents, samples were reported only to 24 hours (rats and female mice) or 48 hours (male mice). Whereas serum levels in female rats and mice dropped to less than 3% of peak concentration by 24 hours, indicating minimal longer-term elimination, the levels in male mice and rats did not drop as quickly and are more suggestive of a β phase. Also noted is that the mouse and rat PK plots in Chang et al. (2008) use a linear y-axis, while the monkey PK plots use a log y-axis. That a β phase would have been clearly observed in male mice and rats is possible had serum sampling been continued for a longer duration, and possibly in female mice and rats had the data simply been plotted with a log y-axis. Serum excretion half-lives for the α and β phases in male monkeys exposed to 10 mg/kg PFBA via i.v. injection were 1.61 ± 0.06 hours and 40.32 ± 2.36 hours, respectively; t_1/2_ values in female monkeys were 2.28 ± 0.14 hours and 41.04 ± 4.71 hours, respectively.

Excretion of PFBA from the serum in humans also was investigated by Chang et al. (2008). In the initial occupational study, baseline PFBA serum concentration was determined in male workers (n = 3) exposed to either PFBA or related fluorinated compounds. Following voluntary removal from the workplace, workers had blood samples taken over 8 days to estimate half-lives of excretion. Given the small sample size of the initial occupational study, a second study was conducted in which seven male and two female workers had blood samples taken immediately before a vacation and upon returning to the production facility (minimum elapsed time was 7 days). For the male workers in the initial study, t_1/2_ of excretion from the serum ranged from 28.6 to 109.7 hours (1.2 to 4.6 days). For the nine workers in the second study, the t_1/2_ ranged from 44 to 152 hours (1.9 to 6.3 days), with an average value of 72 hours (95% confidence interval [CI]: 1.8−4.2 days). Because these workers had been exposed previously for a significant duration and the PK study was conducted over periods ranging from 7 to 11 days, the observed elimination is reasonably presumed to represent β-phase elimination, rather than the initial distribution phase. Although only two female subjects were included in the second study (and their final PFBA serum concentrations fell below the limit of detection), their estimated t_1/2_ values (118 hours and 56 hours) fell within the range of t_1/2_ values reported for males (44–152 hours). Therefore, although sex differences in serum excretion in rodent species appear strong, the data in cynomolgus monkeys and humans do not indicate such a difference.

Measurements for four of the subjects evaluated by Chang et al. (2008) fell below the lower limit of quantification (LLOQ) when the second blood sample was taken, requiring the authors to assume a value of LLOQ/√2 for those values. This approach introduces considerable uncertainty, so the population half-life excluding those individuals was estimated as described in Appendix C.2 to obtain a half-life of 67.9 hours (rather than the author-reported arithmetic mean value of 72 hours). This revised estimate will be used for subsequent analysis.

Using an assumed BW^0.75^ scaling and standard species BWs of 0.25 kg in rats and 80 kg in humans, the half-life in humans is predicted to be 4.2 times greater than in rats. Given half-lives of 9.22 and 1.76 hours, respectively, in male and female rats (oral dose values), one would then predict half-lives of 37.8 hours in men and 7.2 hours in women. Although the value for men based on the BW^0.75^ scaling approach is within a factor of 2 of the value determined by Chang et al. (2008), BW^0.75^ scaling is not based on data for this class of chemicals (i.e., serum binding and clearance mechanisms are known to occur for PFAS). For example, EPA’s Recommended Use of Body Weight 3/4 as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011) does not mention serum binding; it does include references related to VOCs, drugs, and overall metabolism (with metabolism a significant component in the clearance of many other toxic chemicals) but does it cite papers evaluating the pharmacokinetics of PFAS. These results for PFBA indicate that BW^0.75^ scaling would lead to a lower prediction of human health risk at a given exposure than dosimetric scaling based on the empirical data. Further, although only two women participated in the Chang et al. (2008) study, that the observed elimination for them was 8 and 16 times slower than predicted by BW^0.75^ is an unlikely occurrence—even given the small sample size—and using of BW^0.75^ scaling (applied to the half-life in female rats) could underpredict the risk of exposure by an order of magnitude. Therefore, use of BW^0.75^ as an alternative means of extrapolation is not considered further here.

Excretion in the urine appears to be the major route by which PFBA is excreted from the body. Female rodents (rats: 100.68%−112.37%; mice: 65.44%−67.98%) are observed to have higher percentages of the dose excreted in urine at 24 hours compared to male rodents (rats: 50.99%−90.16%; mice: 34.58%−35.16%). This is consistent with evidence that organic anion transporters (OAT) expressed in the kidneys of rodents reabsorb PFAS (Weaver et al., 2010; Yang et al., 2009) and are more highly expressed in male rodents (Ljubojevic et al., 2007; Ljubojevic et al., 2004; Buist et al., 2002; Cerrutti et al., 2002; Kato et al., 2002). Both Yang et al. (2009) and Weaver et al. (2010), however, observe that PFBA is not an active substrate of organic anion transporters OAT1, OAT2, or OATP1a1. Therefore, although the observed sex difference in urinary excretion of PFBA is consistent with the literature for reabsorption of PFAS in general in the kidney in male rodents, the mechanism for this reabsorption for PFBA specifically is not currently known. Sex differences in urinary excretion rates are not observed in primates, with both female and male cynomolgus monkeys having rates similar to those of male mice (36.2% and 41.69%, respectively) Chang et al. (2008). The excretion of PFBA in feces in rats and mice was very low compared with the excretion in urine, but higher in mice than in rats (4.10%−10.92% and 0.16%−2.99%, respectively).

### 3.1.5 Summary

PFBA clearance (CL) data, which can be used to estimate the average blood concentration for a given dose, are available for mice and rats. For mice, the average CL from PK experiments at 10 and 30 mg/kg is suggested for use in animal-human extrapolation. For rats, the average of values estimated from i.v. and oral exposure to 30 mg/kg is suggested.

Direct comparison of animal and human data requires consideration of observed half-lives because such data are available in humans, but CL cannot be directly estimated in humans. Collectively, although the PFBA excretion half-lives for male and female rats appear shorter than for male and female mice, respectively, data suggest a strong sex-specific pharmacokinetic difference for both species (i.e., females appear to have a much faster excretion rate than males). Humans have a longer serum excretion half-life (~day) than rodents (~hour). Although data in male mice and rats might indicate a longer β phase elimination, the lower dose data in male mice are reasonably fit using a single half-life (one-compartment model) as are the i.v. and oral data at the single dose given to rats (30 mg/kg); the female mouse and rat data are likewise fit well by a one-compartment model (Chang et al., 2008). Therefore, although a longer elimination phase might be evident if additional data were available, the estimated total clearance is unlikely to differ substantially from the estimates provided here. The α-phase half-lives in monkeys (1.6–2.3 hours) are similar to the half-life obtained for female mice (2.8–3.1 hours) and female rats (1–1.8 hours) but are substantially shorter than the half-life observed in male mice (13–16 h at lower doses) and male rats (6–9 hours). The β-phase half-life in monkeys (1.7 days) is considerably longer than any of these rodent values but is comparable to the lower end of the range for human subjects (1.8–2 days), although roughly one-half the average among humans (3 days). As noted above, these human half-lives are expected to represent β-phase, considering the period of observation vs. exposure.

Human CL can be estimated using the PK relationship, 𝐶𝐿 = 𝑉_𝑑_ ∙ 𝑙𝑛(2)/𝑡_0.5_. Because human data do provide a value of t_1/2_, only a value of V_d_ is needed to determine CL. As discussed above, however, one can reasonably anticipate that V_d_ in humans is similar to that in other primates based on the similarity in physiology and assumptions common to PBPK modeling. This similarity is illustrated on the basis of PBPK models for PFOA and PFOS Loccisano et al. (2011) from which V_d_ in humans is predicted to be within 7% of the value for monkeys for those two PFAS. Thus, this choice seems appropriate for estimating human clearance of PFBA. Using the average human half-life of 67.9 hours (2.8 days) from Appendix C.2 and average of male and female monkey V_d_ of 0.485 L/kg from Chang et al. (2008) the resulting human clearance is 0.12 L/kg-day.

Table 3-2 provides a summary of PFBA pharmacokinetics.

Table 3-2 Summary of pharmacokinetics of serum perfluorobutanoic acid (PFBA) (mean ± standard error)

Species/sex | Study design | Excretion half-life (h) | AUC (μg-h/mL) | Clearance (mL/h) | Clearance (L/kg-d)^a^ | Volume of distribution (mL/kg)
Rats
Male | 30 mg/kg i.v. dose | 6.38 ± 0.53 | 1,090 ± 78 | 7.98 ± 0.57 | 0.661 | 253 ± 6
Male | 30 mg/kg oral dose | 9.22 ± 0.75 | 1,911 ± 114 | 4.63 ± 0.28 | 0.377 | 209 ± 10
Female | 30 mg/kg i.v. dose | 1.03 ± 0.03 | 239 ± 5 | 27.65 ± 0.55 | 3.01 | 187 ± 3
Female | 30 mg/kg oral dose | 1.76 ± 0.26 | 443 ± 42 | 14.32 ± 1.36 | 1.63 | 173 ± 21
Mice
Male | 10 mg/kg oral dose | 13.34 ± 4.55 | 1,026 ± 248 | 0.35 ± 0.09 | 0.234 | 152
Male | 30 mg/kg oral dose | 16.25 ± 7.19 | 2,869 ± 6,116 | 0.37 ± 0.80 | 0.251 | 296
Male | 100 mg/kg oral dose | 5.22 ± 2.27 | 3,630 ± 530 | 0.98 ± 0.14 | 0.661 | 207
Female | 10 mg/kg oral dose | 2.87 ± 0.30 | 387 ± 14 | 0.76 ± 0.03 | 0.620 | 107
Female | 30 mg/kg oral dose | 3.08 ± 0.26 | 999 ± 42 | 0.87 ± 0.04 | 0.720 | 134
Female | 100 mg/kg oral dose | 2.79 ± 0.30 | 1,760 ± 88 | 1.67 ± 0.08 | 1.36 | 207
Monkeys
Male | 10 mg/kg i.v. dose | 1.61 ± 0.06 (α); 40.32 ± 2.36 (β) | 112 ± 6 | 494 ± 61 | 2.14 | 526 ± 68
Female | 10 mg/kg i.v. dose | 2.28 ± 0.14 (α); 41.04 ± 4.71 (β) | 159 ± 8 | 224 ± 19 | 1.51 | 443 ± 59
Humans
Males and females | NV | Study 1: 28.6−109.71 Study 2: 72 (mean) | NV | NV | NV | NV

AUC = area-under-the-concentration-curve, NV = not available.

All data from Chang et al. (2008). All data from Chang et al. (2008).

a Calculated as dose (mg/kg) × (1,000 μg/mg) × (24 h/d) / ((AUC μg-h/mL) × (1,000 mL/L)).

The mouse PK data of Chang et al. (2008) clearly indicate nonlinear elimination, with more rapid clearance at higher concentrations consistent with a mechanism of saturable renal resorption. Since there is only a modest difference in clearance between the lowest two doses (10 and 30 mg/kg-day) it is reasonable to assume first-order elimination around and below these dose levels in mice. However, use of the low-dose clearance for effects associated with higher doses is likely to over-predict the corresponding HED, since mouse clearance is higher at higher exposures.

Unfortunately, the single dose used for PK in rats is not sufficient to demonstrate when saturation might occur in that species. The data and model fits shown by Chang et al. (2008), particular for the i.v. administration, appear quite consistent with first-order elimination assumed in their analysis. Hence, for the purposes of the current analysis, it is assumed that the estimated CL is applicable to 30 mg/kg-day doses or below and to avoid extrapolation above that dose.

Some mechanistic insight can be gained by comparing the clearance values described above with species-specific glomerular filtration rate (GFR), with and without adjustment for serum protein binding. Davies and Morris (1993) summarized GFR for multiple species. Considering the time period when those data were collected, it seems appropriate to use the species average BW values listed in Table III of Davies and Morris (1993): 0.02 kg for the mouse, 0.25 kg for the rat, and 70 kg for the human. Using those, the GFR/BW for these species are 20.2 L/kg-day in mice, 7.55 L/kg-day in rats, and 2.57 L/kg-day in humans. which are, respectively, 83 and 32 times higher than PFBA clearance in male and female mice (average of values at lowest two doses), 14.5 and 3.3 times higher than the average for male and female rats from Chang et al. (2008), and 21 times higher than the human PFBA clearance estimated above.

Binding to serum proteins plays a likely role in these very large differences. Chen and Guo (2009) measured the binding of PFBA to human serum albumin and obtained a binding constant of (1.1 ± 0.1) × 10^6^ M^-1^ for albumin site I with no observed binding to the Trp site or site II. Using a representative serum albumin concentration of 40 mg/mL = 6 × 10^-4^ M, the predicted free fraction of PFBA is f_free_ = 0.0015. This binding may play a role in the limiting the rate of the renal excretion of PFBA, in addition to the role played by renal transporters. Using this value, GFR × f_free_ = 0.03 L/kg-day in mice, 0.01 L/kg-day in rats, and 0.004 L/kg-day in humans. The measured CL for male mice (0.23−0.66 L/kg-day) is 8- to 22-fold higher than GFR× f_free_ and the CL for female mice (0.62−1.36 L/kg-day) is 21- to 45-fold above GFR× f_free_. Even more significantly, CL in rats is as much as 300-fold higher than the corresponding GFR× f_free_, and the estimated CL in humans (0.12 L/kg-day) is 30-fold higher than the corresponding GFR× f_free_. The source of these apparent discrepancies is unclear. It is reasonable to expect that plasma protein binding will limit the clearance of PFBA. However, these results indicate that either f_free_ is significantly under-estimated or that clearance is not strictly limited to the free fraction (estimated from an in-vitro binding constant). Binding and dissociation are dynamic processes, and it may be that as blood passes through the glomerulus and filtration occurs, some portion of the albumin-bound PFBA is sufficiently labile to dissociate and also be cleared. A mathematical model that incorporates the kinetics of plasma binding and release to describe uptake of drugs by the brain has been previously described by Robinson and Rapoport (1986), but adaptation of this model to renal clearance of PFBA would require measurement of the separate rates of association and dissociation, data which have not been reported.

Another possible explanation is from imperfect filtering of albumin by the glomerulus, leading to some urinary excretion of albumin which may carry bound PFBA. Van Camp et al. (1990) observed an albumin excretion rate in female rats on normal diets (i.e., control animals) of about 1 mg/day, which corresponds to a clearance of 0.025 mL/day given a serum albumin concentration of 40 mg/mL. The urine samples were collected at the mid-point of the experiment. Based on the BW reported on the first and final days of the experiment, the rats at this time were around 0.14 kg, hence had an albumin CL of 1.8 × 10^-4^ L/kg-day; i.e., about four orders of magnitude lower than the PFBA CL in female rats (see Table 3-2). While kidney damage is known to increase albumin excretion (for example, a high phosphate diet increased albumin excretion in female rats about 50-fold (Matsuzaki et al., 2002)), an increase of 10,000-fold occurring within the 24-hour time-frame of the PK experiments, when kidney toxicity has not been reported for PFBA exposure in rats, seems rather unlikely. However, if only 5% of the bound PFBA is sufficiently labile to be available for clearance, that would be consistent with the empirical data and estimated clearance rates.

## 3.2 NONCANCER EVIDENCE SYNTHESIS AND INTEGRATION

For each potential health effect discussed below, the synthesis describes the database of available studies and the array of the experimental animal study results (the primary evidence available for this PFAS) across studies. Effect levels presented in these arrays are based on statistical significance^9^ or biological significance, or both. Examples relevant to interpretations of biological significance include directionality of effect (e.g., statistically significantly decreased cholesterol/triglycerides are of unclear toxicological relevance) and tissue-specific considerations for magnitude of effect (e.g., statistically nonsignificant increase of ≥10% in liver weight might be considered biologically significant). A significant finding at a single, lower dose level but not at multiple, higher dose levels might be interpreted as potentially spurious. For this section, evidence to inform organ/system-specific effects of PFBA in animals following developmental exposure is discussed in the individual organ/system-specific sections (e.g., liver effects after developmental exposure are discussed in the liver effects sections). Evidence of other effects informing potential developmental effects (e.g., vaginal opening, eyes opening) is discussed in the “Developmental Effects” section.

### 3.2.1 Thyroid Effects

#### Human Studies

Two studies reported on the association between PFBA exposure and thyroid hormones or disease. One study on congenital hypothyroidism was considered uninformative (https://hawcprd.epa.gov/rob/study/100517935/)^10^ due to concerns with participant selection, confounding, and exposure measurement (Kim et al., 2016). In one low confidence (https://hawcprd.epa.gov/rob/study/100517927/) study Li et al. (2017b) examining thyroid hormones among participants without thyroid disease, inverse associations with thyroxine (T4), free triiodothyronine (T3), and thyroid-stimulating hormone (TSH) were reported. Among the thyroid hormones measured, only TSH demonstrated a statistically significant association (Pearson correlation coefficient = −0.348, p < 0.01).

#### Animal Studies

Two high confidence studies reported in two unpublished reports and one publication from the same research group evaluated the effects of PFBA exposure on the thyroid, specifically hormone levels, histopathology, and organ weight (Butenhoff et al., 2012c; Butenhoff et al., 2012a; van Otterdijk, 2007a, b) following oral exposure (via gavage) of SD rats.^11^ Some outcome-specific considerations for study evaluations were influential on the overall study rating for thyroid effects, but none of these individual domain-specific limitations were judged likely to be severe or to have a notable impact on the study results; all studies considered further in this section were rated as high or medium confidence (see Figure 3-1). For more information on outcome-specific considerations for study evaluations, please refer to the study evaluations in the HAWC PFBA project page (https://hawc.epa.gov/assessment/100500073/).

Figure 3-1 Evaluation results for animal studies assessing effects of perfluorobutanoic acid (PFBA) exposure on the thyroid (see interactive data graphic for rating rationales (https://hawcprd.epa.gov/summary/visual/100500265/))

##### Organ weight

Absolute and relative thyroid weights (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-thyroid-weight-effect-size-animal/) were statistically significantly (p < 0.01) increased (~2-fold) at the end of treatment in male rats exposed to 6 or 30 mg/kg-day via oral gavage for 28 days compared with controls. Organ weights, however, were increased only ~50% at 150 mg/kg-day, and this difference was not statistically significant. Thyroid weights were not significantly increased in male rats following the recovery period or in female rats following the treatment or recovery period. Thyroid weight was not measured in the rats exposed to NH_4_^+^PFB for 90 days (Butenhoff et al., 2012a; van Otterdijk, 2007b).

##### Thyroid hormones

Male rats exposed to NH_4_^+^PFB for 28 days via gavage exhibited significantly decreased total thyroxine (T4) (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-total-t4-effect-size-animal/) and free T4 (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-free-t4-effect-size-animal/) [underlined: (fT4)] levels compared with controls (see Table 3-3 and Figure 3-2). Total T4 was reduced 59%, 66%, and 79% and free T4 was reduced 46%, 50%, and 66% at 6, 30, and 150 mg/kg-day, respectively (Butenhoff et al., 2012a; van Otterdijk, 2007a). Free T4 concentrations had returned to control levels at all doses 21 days after exposure ended, but total T4 levels remained decreased in the 150 mg/kg-day group (−23%). TSH levels were not affected by NH_4_^+^PFB at any exposure level. No treatment-related effects on any of the thyroid hormone measures were observed in female rats exposed for 28 days (Butenhoff et al., 2012a; van Otterdijk, 2007a)

Table 3-3 Percent change in thyroid hormones due to perfluorobutanoic acid (PFBA) exposure in short-term and subchronic oral toxicity studies

Animal group | Dose (mg/kg-d)
Animal group | 1.2 | 6 | 30 | 150
Free T4
28 d; male S-D rats; Butenhoff et al. (2012a) | | −46 | −50 | −66
28 d; female S-D rats; Butenhoff et al. (2012a) | | −0.5 | +18 | −25
90 d; male S-D rats; Butenhoff et al. (2012a) | ^a^ | −9b | −30 ^b^
90 d; female S-D rats; Butenhoff et al. (2012a) | −6 | +27 | −15
Total T4
28 d; male S-D rats; Butenhoff et al. (2012a) | | −59 | −66 | −79
28 d; female S-D rats; Butenhoff et al. (2012a) | | −8 | +27 | −31
90 d; male S-D rats; Butenhoff et al. (2012a) | +13 | −15 | −39
90 d; female S-D rats; Butenhoff et al. (2012a) | +16 | +14 | −21

Bolded cells indicate statistically significant changes compared to controls (except for the 6 mg/kg-d and 30 mg/kg-d dose groups for free T4 in male rats exposed for 90 d, tests for statistical significance in those cases were made to the 1.2 mg/kg-d group [see footnote b]); shaded cells represent doses not investigated in the individual studies.

a No sample for the control group was available due to insufficient sample volume for assay.

b Comparison is made to the 1.2 mg/kg-d dose group.

Decreased total T4 and free T4 levels also were observed in male rats exposed to NH_4_^+^PFB via gavage for 90 days (Butenhoff et al., 2012a; van Otterdijk, 2007b). Total T4 increased 13% and decreased 15% following 1.2 and 6 mg/kg-day, respectively. In male rats exposed to the highest dose tested (30 mg/kg-day NH_4_^+^PFB), total T4 was significantly reduced by 39%. Free T4 was also reduced in the 30-mg/kg-day dose group, but comparison to a control group was not possible due to insufficient sample volume in the control group. The decrease in free T4, however, appeared to be monotonic with increasing dose, and the decrease in the 30-mg/kg-day group (30%) was statistically significant compared with the free T4 concentration in the 1.2 mg/kg-day group. No statistically significant treatment-related effects were observed in female rats exposed to NH_4_^+^PFB for 90 days, although total T4 was nonsignificantly decreased at the highest dose [30 mg/kg-day; (Butenhoff et al., 2012a; van Otterdijk, 2007b)].

Figure 3-2 Thyroid hormone response to ammonium perfluorobutanoate (NH_4_^+^PFB) exposure (see interactive data graphic and rationale for study evaluations for thyroid hormone effects (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-thyroid-effects/) in Health Assessment Workspace Collaborative [HAWC])

##### Histopathology

Butenhoff et al. (2012a); van Otterdijk (2007a, 2007b) also investigated thyroid histopathological and histomorphological effects in male and female rats resulting from NH_4_^+^PFB exposure (see Table 3-4 and Figure 3-3). Incidence of follicular hypertrophy/hyperplasia (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfbs-thyroid-histopathology-effect-size-animal/) increased in males exposed to 30 mg/kg-day (9/10) and 150 mg/kg-day (7/10) for 28 days compared with control (3/10), with all observed lesions in the 30 mg/kg-day dose group graded by the study authors as “minimal” severity (trend test p = 0.0498; Cochran-Armitage test, performed by EPA). In the 150 mg/kg-day dose group, three of the seven affected animals were observed to have lesions graded as “slight,” a severity level greater than “minimal”; the remaining four affected animals were graded as having “minimal” lesions. Female rats treated for 28 days with 150 mg/kg-day NH_4_^+^PFB had 40% incidence (4/10) of minimal lesions compared with 3/10 minimal lesions observed in the control group. Thyroid histopathology was not examined in the 30-mg/kg-day females and no effects were noted in the 6-mg/kg-day group (although the thyroid of only one animal was available for testing in this group). No treatment-related effects were observed in the recovery groups. In contrast to the histopathological examination, the histomorphometric analysis reported no effects on thyroid cell height or colloidal area in either the treatment or recovery groups. Follicular hypertrophy/hyperplasia also was observed to increase in male rats exposed to 30 mg/kg-day (9/10) for 90 days compared to controls when considering all lesions (9/10 vs. 4/10; Cochran Armitage trend p = 0.0108) and lesions were graded “slight” (5/10 vs. 0/10; Cochran Armitage trend p < 0.0001).

Table 3-4 Incidence and severity of thyroid follicular hypertrophy/hyperplasia due to perfluorobutanoic acid (PFBA) exposure in short-term and subchronic oral toxicity studies

Animal group (n = 10 in all groups) | Dose (mg/kg-d)
Animal group (n = 10 in all groups) | 0 | 1.2 | 6 | 30 | 150
28 d; male S-D rats; Butenhoff et al. (2012a) | 3 (min) | | 3 (min) | 9 (min) | 7 (4 min, 3 mild)
90 d; male S-D rats; Butenhoff et al. (2012a) | 4 (min) | 6 (min) | 4 (min) | 9 (4 min, 5 mild)

Bolded cells indicate statistically significant changes compared with controls; shaded cells represent doses not investigated in the individual studies. Severity normalized to four points scaled as follows: min = minimal severity; mild = mild/slight severity; mod = moderate severity; sev = marked severity.

Figure 3-3 Thyroid histopathology and organ-weight responses to ammonium perfluorobutanoate (NH_4_^+^PFB) exposure (see interactive data graphic and rationale for study evaluations for other thyroid effects (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-other-thyroid-effects-2/) in Health Assessment Workspace Collaborative [HAWC])

#### Mechanistic Evidence and Supplemental Information

Thyroid effects observed in the PFBA database consist of increased thyroid weight, increased incidence of follicular hypertrophy/hyperplasia, and decreased levels of thyroxine (total and free T4). Overall, a pattern of decreased hormone levels with corresponding alterations in tissue weight and histopathology in the absence of an increase in TSH was observed. However, the coefficient of variation for TSH in controls in the 90-day study (Butenhoff et al., 2012a; van Otterdijk, 2007a, b) ranged from 40%−55%, compared to 13%−25% for free T_4_. The lack of an observation of increased TSH may be due to difficulties in detecting relatively small changes in TSH given the assay used in the study. While there is uncertainty in the reliability of the TSH measurements and patterns of TH changes in animals may not translate perfectly to human clinical definitions, decreases in T4 alongside normal levels of TSH is consistent with the human clinical condition referred to as hypothyroxinemia [see additional discussion in (U.S. EPA, 2018b)]. Although the PFBA database is limited to two adult exposure studies (28- and 90-d) (Butenhoff et al., 2012a; van Otterdijk, 2007a, b) in rats the observed thyroid hormone effects are supported by supplemental information from structurally related PFAS (PFBS and PFHxA).

Decreases in thyroid hormones (total T3, total T4, and free T4) were observed in PFBS-exposed pregnant mice and gestationally exposed female mouse offspring at ≥200 mg/kg-day (Feng et al., 2017) and in adult female and male rats following short-term exposures of ≥62.6 mg/kg-day (NTP, 2019). Increased TSH was reported in mouse dams and in offspring during development of the reproductive system (PND 30) following gestational exposure Feng et al. (2017), but no changes were noted in rats exposed to PFBS as adults . Increased TSH was reported in mouse dams and in offspring during development of the reproductive system (PND 30) following gestational exposure Feng et al. (2017), but no changes were noted in rats exposed to PFBS as adults (NTP, 2019), a pattern consistent with the observed changes following adult PFBA exposure. Thyroid weight and histopathology were not changed after short-term exposure to PFBS in adult male or female rats (NTP, 2019).

Although the available evidence for PFHxA appears to provide weaker support for endocrine effects than studies on PFBA or PFBS (see public comment draft for PFHxA; (U.S. EPA, 2021b), the only study in the PFHxA database of animal toxicity studies to examine thyroid hormone levels observed that short-term oral exposure to PFHxA altered thyroid hormone levels in male but not female rats (NTP, 2018). Dose-dependent decreases in free and total T4 (25%–73% and 20%–58%, respectively) and to a lesser degree T3 (18%–29%) were observed with no concomitant increase in TSH (NTP, 2018).

Decreased serum T4 or T3 is a key event preceded by disrupted TH synthesis (via multiple possible mechanisms, including thyroid stimulating hormone receptor [TSHR] binding and thyroid peroxidase [TPO] or sodium-iodide symporter [NIS] inhibition) and results in a myriad of downstream neurodevelopmental outcomes, including altered hippocampal anatomy/function and hearing deficit. Thyroid hormones are critically important for proper brain development (Bernal, 2015; Miller et al., 2009; Williams, 2008; Crofton, 2004; Morreale de Escobar et al., 2004; Zoeller and Rovet, 2004; Howdeshell, 2002) because they directly influence neurodevelopmental processes, such as neurogenesis, synaptogenesis, and myelination (Puig-Domingo and Vila, 2013; Stenzel and Huttner, 2013; Patel et al., 2011). Early in gestation, TH is delivered to the developing fetal brain via placental transfer from the mother to the fetus (Calvo et al., 1990). The mother imparts TH as its sole source until the fetal thyroid gland begins functioning. The fetal gland is completely nonfunctional until late gestation (gestation day [GD] 17), having only minimal functionality until near parturition (GD 22 (Bernal, 2015; Obregon et al., 2007; Morreale de Escobar et al., 2004)), at this point, in rats, approximately 17% of fetal T4 is still derived from the maternal source despite the presence of a newly functioning thyroid gland (G et al., 1990). In humans, these maternal-derived fetal T4 estimates range from 30% to 50% (Obregon et al., 2007; Morreale de Escobar et al., 2004; Vulsma et al., 1989).

Recent mechanistic data in human fetal tissue demonstrates the presence of thyroid receptors and transporters in the brain which suggests the fetal brain has a direct sensitivity to thyroid hormones and supports the decades of observational, genetic, and animal research (Diez et al., 2021; López-Espíndola et al., 2019). In addition, given the importance of thyroid hormones in neurodevelopment in humans and animals, low thyroid hormone status is associated with adverse neurological effects (Stagnaro-Green and Rovet, 2016; Zoeller and Rovet, 2004), and is likely associated with effects in numerous other organ systems, including the heart, bone, lung and intestine (Mullur et al., 2014; Bassett et al., 2007; Mochizuki et al., 2007; Wexler and Sharretts, 2007; Bizzarro and Gross, 2004). Butenhoff et al. (2012a) observed that PFBA not only reduced thyroid function via decreased serum total and free T_4_ but also increased thyroid hormone action in the liver. This pattern of the effects has been seen following exposure to polychlorinated biphenyls (PCBs) and polybrominated diphenyl ethers (PBDEs). For instance, increased TH gene expression in the liver has been shown with a corresponding, inverse reduction in serum total and free T_4_ (Giera et al., 2011) and (Bansal et al., 2014). Following PCB exposure, this complex pattern also occurred with changes in thyroid hormone action in the brain (Bansal and Zoeller, 2008; Zoeller et al., 2000; Zoeller and Crofton, 2000) and (Mullur et al., 2014). Increased thyroid hormone activation in the liver is known to reduce serum cholesterol (Mullur et al., 2014). Butenhoff et al. (2012a) reported decreased serum cholesterol following PFBA exposure; these effects are described in section 3.2.2 “Hepatic Effects”.

Cases of severe maternal and fetal hypothyroidism, which results from iodine deficiency, Hashimoto’s disease, or premature birth, further underscore the importance of maintaining thyroid hormone homeostasis during pregnancy. Several human epidemiological studies have demonstrated key relationships between decreased circulating levels of thyroid hormones, such as T4 in pregnant women and in utero and early postnatal life neurodevelopmental status. For example, neurodevelopmental and cognitive deficits have been observed in children who experienced a 25% decrease in maternal T4 during the second trimester in utero (Haddow et al., 1999). Children born euthyroid but exposed to thyroid hormone insufficiency in utero (e.g., ≤10^th^ percentile free T4), present with cognitive impairments (e.g., decreased intelligence quotient [IQ], increased risk of expressive language disorder) or concomitant abnormalities in brain imaging (Korevaar et al., 2016; Henrichs et al., 2010; Lavado-Autric et al., 2003; Mirabella et al., 2000). This level of T4 insufficiency (<10^th^ percentile), defined as mild-to-moderate thyroid insufficiency, has been shown to correspond to a 15%–30% decrease in T4 serum levels compared to median levels (Finken et al., 2013; Julvez et al., 2013; Román et al., 2013; Henrichs et al., 2010). Animal toxicity studies also have shown that decreases in mean maternal T4 levels of ~10%–17% during pregnancy and lactation elicit neurodevelopmental toxicity in rat offspring (Gilbert et al., 2016; Gilbert, 2011). Human studies also observe that thyroid hormone insufficiency is associated with cognitive deficits in children (Crofton and Zoeller, 2005; Crofton et al., 2005).

There are very few human studies available to inform what percent decrease in T4 might lead to other adverse outcomes. This is mainly due to the nature of epidemiological studies, typically with representative samples analyzed post hoc; many also bin data by “hypothyroid, euthyroid, hypothyroxinemic” based on reference ranges, and then correlate to adverse outcomes. Specifically, three human studies Jansen et al. (2019); Levie et al. (2018); Korevaar et al. (2016) were identified that had sample sizes large enough to capture a wide range of TSH and/or T4 values, which were then correlated to various neurodevelopmental outcomes that could be quantified. However, these studies still do not make direct comparisons from a percent decrease in hormones that would lead to an adverse effect; rather, they stratify their hormone samples by standard deviation to the mean/median, quartiles, etc. Therefore, it’s difficult to make a conclusion in humans regarding what percent of hormone dysfunction is adverse, as those kinds of data are not generated. Additionally, in experimental animal models, there are no definitive values regarding to what degree of T4 reduction is adverse. This is due to several factors, including the existence of multiple thyroid-dependent processes in the brain, which likely have differing spatiotemporal sensitivities. But there are studies that show how graded reductions in T4 can lead to neuronal heterotopia (Gilbert et al., 2014), synaptic transmission defects (Gilbert and Sui, 2008), now and differential gene expression (O’Shaughnessy et al., 2018) and (Sharlin et al., 2010).

There are data gaps in the PFBA developmental toxicity database, including a lack of information on the thyroid and nervous system following gestational exposure. Although short-term PFBA exposure did not appear to alter thyroid hormone levels in nonpregnant adult female rats, thyroid hormone levels fluctuate throughout normal gestation (O’Shaughnessy et al., 2018; Hassan et al., 2017; Pérez et al., 2013; Calvo et al., 1990; Fukuda et al., 1980) as maternal demands to provide the fetus with adequate thyroid hormones. Specifically, serum T4 and T3 normally decline over the course of pregnancy and then rise during the postnatal period (O’Shaughnessy et al., 2018). Thus, although no changes in thyroid hormone levels occurred in nonpregnant rats, that PFBA influences hormone homeostasis differently in pregnant rats during the perinatal period is possible as maternal and fetal hormone demands fluctuate.

Overall, animal studies specific to PFBA and other potentially relevant PFAS provide support for thyroid hormone disruptions which can potentially lead to other effects of concern (e.g., neurodevelopmental effects).

#### Evidence Integration Summary

Inverse associations between PFBA exposure and thyroid hormone levels were observed in the one available informative human study (Li et al., 2017b). Given the low confidence in the study methods and the lack of biological coherence across the hormone changes, however, the available human evidence did not notably contribute to the evidence integration judgment on PFBA-induced thyroid effects (i.e., indeterminate evidence).

The animal evidence comes from two high confidence experiments conducted by the same laboratory (Butenhoff et al., 2012a; van Otterdijk, 2007a, b), which reported PFBA-induced perturbation of the thyroid in one species and sex (male S-D rats) across two different exposure durations. The reported PFBA exposure-induced effects across thyroid hormone measures (i.e., adult males, reductions in total or free T4; T3 was not measured) were consistent, dose dependent, and associated with increasing absolute and relative thyroid weights and histopathology (follicular hypertrophy/hyperplasia). These decreases were large in magnitude (≥50% in some PFBA exposure groups), and perturbations in total T4 were shown to persist at least 21 days after the termination of 90-day exposure to the highest dose (150 mg/kg-day) but not lower doses (in fact, total T4 was increased at 30 mg/kg-day). No effects (e.g., increases) on TSH in exposed rats were observed. The observed pattern of effects on the thyroid (i.e., decreased total and free T4 without a compensatory increase in TSH) after PFBA exposure is consistent with thyroid perturbations following exposure to other PFAS, including the structurally related compound perfluorobutane sulfonate (U.S. EPA, 2021b). Taken together, the consistent changes in total and free T4, thyroid weights, and histopathology across the two available oral PFBA exposure experiments are biologically coherent and plausible.

Several aspects of the animal evidence base decrease the strength or certainty of the evidence. Although there is coherence across different measures of thyroid toxicity in male rats, some effects across durations of exposure are inconsistent: some effects occur in the 28-day study but not in the 90-day study, and the magnitude of change of some effects is larger in the short-term than in the subchronic study. Also, in male rats, for free T4 only, the lack of a control group in animals exposed for 90 days complicates the interpretation of that endpoint.

Although the organ-weight increases and histopathological effects (follicular hypertrophy) observed in Butenhoff et al. (2012a) are consistent with a scenario where serum T4 levels are low but TSH levels are normal, the mechanism by which these changes occurred unclear. Rodents are more sensitive to these histopathological changes (follicular cell hypertrophy), which then can develop into follicular cell tumors (U.S. EPA, 1998a). Increased thyroid follicular cell hypertrophy supports the finding that the thyroid hormone economy is perturbed. The observed changes are likely due to increased metabolism or competitive displacement of T4. That no thyroid effects (e.g., hormone or histopathological changes) were observed in adult nonpregnant females at any dose or treatment duration might be related to PFBA pharmacokinetics because clearance rates in rats are faster in females (compared to males, see Section 3.1.4). Taken together, the available animal studies provided moderate evidence for thyroid effects.

Rodents and humans share many similarities in the production, regulation, and functioning of thyroid hormones. Although differences exist, including the timing of in utero thyroid development and hormone turnover rates, rodents are considered a good model for evaluating the potential for thyroid effects in humans (Zoeller et al., 2007). More specifically, the observed decreases in total or free T4 in the absence of increases in TSH are considered biologically relevant to humans (Crofton, 2004; Lau et al., 2003). TSH is an indicator that the thyroid system has been perturbed, but it does not always change when serum T4 is decreased (Hood et al., 1999). Adverse neurological outcomes have been demonstrated following decreased T4 levels during the early neonatal period with no changes in T3 or TSH (Crofton, 2004). The typical compensatory feedback loop involves microsomal enzymes that induce uridine 5′-diphospho-glucuronosyltransferase (UDP-GT), affecting the thyroid gland by increasing T4 glucuronidation, which in turn reduces serum T4. In this case, the typical response to reduced serum free T4 is an increased production of TSH (Hood and Klaassen, 2000), which can lead to thyroid hyperplasia or rat follicular tumors. In that way, observation of thyroid histopathology can be an indication of perturbations in TSH levels over time even in situations where increased TSH is not observed at the time histopathology is measured (Hood et al., 1999). Rodents have been shown to have a unique sensitivity to thyroid follicular hyperplasia (leading to development of follicular tumors), however, that is considered less relevant to humans (U.S. EPA, 1998a). Nevertheless, the coherent and consistent perturbations to thyroid hormone economy and the resultant increased thyroid histopathology indicates that PFBA is exerting some effect on the thyroid of exposed male rats. Even considering the increased sensitivity of rodents to thyroid follicular hyperplasia compared to humans, thyroid hormone perturbations are considered relevant to humans and might be even more sensitive to change in humans compared to rodents (U.S. EPA, 1998a).

A notable data gap exists for fuller interpretation of the reported thyroid effects. Studies evaluating PFBA effects on neurodevelopment or thyroid measures after developmental exposure (see Section 3.2.3 “Developmental Effects”) were not identified, thus leaving uncertainty on the potential for more sensitive developmental effects of PFBA exposure on the thyroid and nervous systems. During developmental lifestages, such as gestational/fetal and postnatal/early newborn, thyroid hormones are critical in a myriad of physiological processes associated with somatic growth and maturation and survival mechanisms, such as thermogenesis, pulmonary gas exchange, and cardiac development (Sferruzzi-Perri et al., 2013; Hillman et al., 2012). That thyroid hormones are at sufficient levels is essential during times critical to brain development and functioning and in the growth, development, and functioning of numerous organ system processes, including basal metabolism and reproductive, hepatic, sensory (auditory, visual) and immune systems (Forhead and Fowden, 2014; Gilbert and Zoeller, 2010; Hulbert, 2000) (see Mechanistic Evidence and Supplemental Information subsection above). Mammals are more susceptible during perinatal and postnatal lifestages because their compensatory feedback responses are absent or not fully developed and they have low thyroid hormone reserves (Morreale de Escobar et al., 2004; Zoeller and Rovet, 2004). Further, thyroid hormones are critically important in early neurodevelopment as they directly influence neurogenesis, synaptogenesis, and myelination (Puig-Domingo and Vila, 2013; Stenzel and Huttner, 2013). Although the PFBA database lacks information on thyroid hormone levels in exposed pregnant animals or offspring exposed during gestation, these effects have been observed following exposure of mice to the structurally related PFAS, PFBS (U.S. EPA, 2018b). Decreases in total T4 and T3 were observed in dams at GD 20 and offspring at PND 1, 30, and 60, clearly indicating that thyroid hormone levels were perturbed during periods of neurological development. Further, given the evidence is consistent with PFBA, the PFBS assessment identifies developmental neurotoxicity as a database limitation due to the known association between thyroid hormone insufficiency during gestation and developmental neurotoxicity outcomes (U.S. EPA, 2018b). Accordingly, given that developmental neurotoxicity (due to thyroid hormone insufficiency) is a concern following exposure to PFBS, it follows that this concern is relevant to exposure to PFBA during development because of the similarities in thyroid effects across the two PFAS.

Taken together, the evidence indicates that PFBA exposure is likely to cause thyroid toxicity in humans, given relevant exposure circumstances (see Table 3-5). This judgment is based primarily on consistent and biologically coherent results from two high confidence studies (short-term and subchronic study design) in male rats that indicate effects on thyroid hormone levels (T4 without compensatory effects on TSH). These effects on thyroid hormone levels generally occurred at PFBA exposure levels ≥30 mg/kg-day, although some notable effects were observed after exposure to 6 mg/kg-day.

Table 3-5 Evidence profile table for thyroid effects

Evidence Stream Summary and Interpretation | | | | | Inferences and Summary Judgment
Evidence from studies of exposed humans (see Section 3.2.1: Human Studies) | | | | | ⊕⊕⊙; Evidence indicates (likely); Primary basis:; Two high confidence studies in rats ranging from short-term to subchronic exposure; effects observed at ≥6 mg/kg-d PFBA; similar effects for related PFAS; Human relevance:; Effects in rats are considered potentially relevant to humans based on conserved biological processes, and the observed pattern of changes is consistent with potential neurological outcomes following decreased T4 during development (see Section 3.2.1: Mechanistic Evidence and Supplemental Information); Cross-stream coherence:; N/A (human evidence indeterminate); Susceptible populations and lifestages: The developing fetus and children are susceptible to altered thyroid hormone status; the lack of data on thyroid or nervous system effects following gestational exposure is a data gap.
Studies and confidence | Summary of key findings | Factors that increase certainty | Factors that decrease certainty | Judgments and rationale
Thyroid Hormones; 1 low (https://hawcprd.epa.gov/study/100517927/) confidence study | - Single study reporting inverse associations with free T4, free T3, and TSH; only TSH was statistically significant | - No factors noted | - Lack of coherent associations across hormones; - Imprecision | ⊙⊙⊙; Indeterminate
Evidence from in vivo animal studies (see Section 3.2.1: Animal Studies)
Studies and confidence | Summary of key findings | Factors that increase certainty | Factors that decrease certainty | Judgments and rationale
Thyroid Hormones; 2 high confidence studies in adult rats:; - 28-d; - 90-d | - Decrease in free and total T4 in male rats at >6 mg/kg-d; - Decrease in T4 with no increase in TSH | - Consistent increases in males across all studies; - Dose-response gradient; - Coherence of decreased T4 with histopathology; - Magnitude of effect, up to 79%; - High confidence studies | - Potential lack of expected coherence (no compensatory TSH increase to T4 decrease) | ⊕⊕⊙; Moderate; Findings considered adverse based on consistent and biologically coherent results for thyroid hormone levels, organ weights, and histopathology. The observation of effects only in males might be explained by pharmacokinetics. Uncertainties remain as to how organ weights and histopathology are affected in the absence of TSH increases.
Histopathology; 2 high confidence studies in adult rats:; - 28-d; - 90-d | - Follicular hypertrophy/hyper plasia observed in male rates at 30 mg/kg-d; - No histopathological effects at 150 mg/kg-d (after short-term exposure) | - Consistent follicular hypertrophy/hyperplasia in male rats across studies; - Coherence of hypertrophy with T4 decreases; - High confidence studies | - Potential lack of expected coherence (no change in TSH levels); - Unexplained lack of significant effects at highest tested dose
Organ Weight; 1 high confidence study in adult rats:; - 28-d | - Increase in thyroid weight (absolute and relative) at 6 and 30 mg/kg-d; - No change in thyroid weight at 150 mg/kg-d | - Magnitude of effect, >2-fold increases; - High confidence study | - Potential lack of expected coherence (no change in TSH levels); - Unexplained lack of significant effects at highest tested dose
Mechanistic evidence and supplemental information (see subsection above)
Summary of key findings, interpretation, and limitations | | | | Evidence stream judgment
Key findings and interpretation:; - PFBA-induced thyroid changes similar to those for related PFAS (i.e., PFBS and, although the evidence is weaker, PFHxA); - Findings for PFBS indicate the potential for effects of concern during development; Limitations: No PFBA-specific mechanistic evidence informing thyroid effects | | | | Findings for related PFAS support the plausibility of findings for PFBA, and the potential for effects of concern with PFBA exposure during development

### 3.2.2 Hepatic Effects

#### Human Studies

One epidemiological study reported on the relationship between PFBA exposure and serum biomarkers of liver injury. This study Nian et al. (2019a) This study Nian et al. (2019a) was cross-sectional and was classified as medium confidence (https://hawcprd.epa.gov/rob/study/100517939/) given minor concerns over participant selection, outcome ascertainment, and confounding. Sensitivity was considered deficient due to limited exposure contrast for PFBA (detected in 70%, median [interquartile range (IQR)] = 0.15 ng/mL [0.01−0.51 ng/mL]), which likely reduced the study’s ability to detect an effect. The study found no association between serum levels of alanine aminotransferase (ALT), aspartate aminotransferase (AST), total protein, alkaline phosphatase (ALP), γ-glutamyl transferase (GGT), total bilirubin, or cholinesterase with PFBA exposure, but given the sensitivity concerns, this is difficult to interpret.

In addition, one low confidence (https://hawcprd.epa.gov/rob/study/100517925/) cross-sectional study Fu et al. (2014) examined the association between PFBA exposure and blood lipids. No association was reported; however, the exposure levels in the study population were very low with narrow contrast (median [IQR] = 0.1 [0.03–0.2] ng/mL), so the study had poor sensitivity to detect an effect.

#### Animal Studies

Hepatic effects were evaluated in multiple high and medium confidence, short-term and subchronic studies in rats and mice (Butenhoff et al., 2012a; Foreman et al., 2009; van Otterdijk, 2007a, b; Permadi et al., 1993; Permadi et al., 1992) and in one high confidence developmental toxicity study in mice (Das et al., 2008). Some outcome-specific considerations for study evaluations were influential on the overall study rating for liver effects, but none of these individual domain-specific limitations were judged as likely to be severe or have a notable impact on the study results, and all studies considered further in this section were rated as high or medium confidence (see Figure 3-4). For more information on outcome-specific considerations for study evaluations, please refer to the study evaluations in the HAWC PFBA database.

Figure 3-4 Evaluation results for animal studies assessing effects of perfluorobutanoic acid (PFBA) exposure on the liver (see interactive data graphic for rating rationales (https://hawcprd.epa.gov/summary/visual/100500267/))

One low confidence, short-term study also reported hepatic effects (Ikeda et al., 1985). This study was judged as low confidence given concerns over allocation of animals, reporting/attrition concerns, characterization of the test compound, and endpoint sensitivity.

Endpoints evaluated in the studies reporting liver effects include liver weights, histopathological changes, and serum biomarkers of effect.

##### Organ weight

Short-term and subchronic exposure studies consistently demonstrated increased liver weight in rodents exposed to PFBA (see Table 3-6 and Figure 3-5). Liver weight is commonly reported as either absolute weight or relative to body weight. In general, relative liver weight is the preferred metric as it accounts for individual variations in body weight, either due to the exposure being studied or to interindividual variability. Both absolute and relative liver weight are presented in this section for the sake of completeness; results based on absolute liver weight closely track those for relative liver weight.

Table 3-6 Percent increase in relative liver weight due to perfluorobutanoic acid (PFBA) exposure in short-term and subchronic oral toxicity studies

Animal group | Dose (mg/kg-d)
Animal group | 1.2 | 6 | 30 | 35 | 150 | 175 | 350
28 d; male S-D rats; Butenhoff et al. (2012a); van Otterdijk (2007a) | | 5 | 24 | | 48
28 d; female S-D rats; Butenhoff et al. (2012a); van Otterdijk (2007a) | | −1 | 0 | | −3
90 d; male S-D rats; Butenhoff et al. (2012a); van Otterdijk (2007a) | 9 | 7 | 33
90 d; female S-D rats; Butenhoff et al. (2012a); van Otterdijk (2007a) | 0 | −3 | 3
28 d; PPARα wild-type male SV/129 mice; Foreman et al. (2009) | | | | 61 | | 101 | 112
28 d; humanized PPARα male SV/129 mice; Foreman et al. (2009) | | | | 38 | | 63 | 81
28 d; PPARα null male SV/129 mice; Foreman et al. (2009) | | | | 3 | | 1 | 7
Pregnant P_0_ female CD-1 mice on GD 18; Das et al. (2008) | | | | 9 | | 28 | 32
Nonpregnant P_0_ female CD-1 mice on GD 18; Das et al. (2008) | | | | 14 | | 32 | 29
F_1_ male and female CD-1 mice on PND 1; Das et al. (2008) | | | | 9 | | 30 | 41

Bolded cells indicate statistically significant changes compared with controls; shaded cells represent doses not investigated in the individual studies.

The only null study Ikeda et al. (1985) reported that relative liver weight (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-thyroid-weight-effect-size-animal-short-term/) was not increased over controls in male S-D rats exposed to 0.02% PFBA in the diet for 2 weeks (approximately 20 mg/kg-day). This study was judged low confidence, however, on the basis of concerns over reporting, exposure characterization, and endpoint sensitivity/selectivity. Conversely, following 10 days of dietary exposure to 0.02% PFBA, relative liver weight was increased 38% in male C57Bl/6 mice in a medium confidence study (Permadi et al., 1993). Twenty-eight days of daily gavage exposure to ≥35 mg/kg-day PFBA significantly increased relative liver weights (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-liver-weight-effect-size-animal-short-term-28/) in adult male wild-type (+/+) or humanized PPARα (hPPARα) Sv/129 male mice (Foreman et al., 2009). The relative liver weight (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-liver-weight-effect-size-animal-short-term-28/) of wild-type male mice was increased by 61%, 101%, and 112% at 35, 175, and 350 mg/kg-day, respectively. Increased relative liver weight was also observed in these same dose groups in humanized PPARα (hPPARα) male mice, although they were somewhat less than those observed in wild-type mice: 38%, 63%, and 81%. Relative liver weight was not changed in PPARα null (−/−) mice (Foreman et al., 2009). A similar profile of increased relative liver weight also was observed in male S-D rats exposed to ≥30 mg/kg-day NH_4_^+^PFB via oral gavage for 28 days (Butenhoff et al., 2012a; van Otterdijk, 2007a). Relative liver weights were increased 24% and 48% at 30 and 150 mg/kg-day. Relative liver weights in both dose groups were observed to return to control levels following a 21-day recovery period. Female rats exposed at the same dose levels experienced no increases in relative liver weights (1%−3% decrease).

Similar to increases following 28-day exposures, relative liver weights (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-liver-weight-effect-size-animal-subchronic/) also were observed to increase in male S-D rats exposed to NH_4_^+^PFB via oral gavage for 90 days (Butenhoff et al., 2012a; van Otterdijk, 2007b), with relative liver weights increased 33% at 30 mg/kg-day. As with the short-term exposure, relative liver weights returned to control values following a 21-day recovery period after termination of subchronic exposure. As observed in the short-term study, exposure to NH_4_^+^PFB for 90 days did not increase liver weights in female rats (3% decreases to 3% increases). In a developmental toxicity study in CD-1 mice, exposure to NH_4_^+^PFB via oral gavage increased relative (to body weight) liver weights (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-liver-weight-effect-size-animal-developmental/) in pregnant (measured on GD 18) and nonpregnant P_0_ females at ≥175 mg/kg-day (Das et al., 2008). Relative liver weights were increased by 28% and 32% at 175 and 350 mg/kg-day (respectively) in pregnant mice, whereas relative liver weights were increased 32% and 29% in nonpregnant mice at the same dose levels. No effect on liver weights was observed in the subset of dams followed until after weaning (PND 22). Similar magnitudes of relative liver weight increase also were observed in F_1_ animals at PND 1: 30% and 41% at 175 and 350 mg/kg-day, respectively. In animals at PND 10, however, no change in relative liver weights was observed. The lack of an effect on PND 10 in F_1_ or P_0_ animals on PND 22 could be because these animals were not exposed during lactation and therefore had a 10- or 22-day recovery period compared with offspring or dams whose liver weights were measured on PND 1 and GD 17. This observation of no effect following a recovery period is consistent with the findings of the subchronic and short-term exposures in adult animals (Butenhoff et al., 2012a; van Otterdijk, 2007a, b).

Although not an oral toxicity study, Weatherly et al. (2021) also observed statistically significant increases in relative liver weight (up to 60% increases) in mice dermally exposed to PFBA.

In conclusion, effects on relative liver weights in adult male rats and mice were observed at ≥30 or 35 mg/kg-day following subchronic or short-term exposures (respectively), whereas effects in adult pregnant and nonpregnant female mice (exposed during pregnancy) and their offspring were observed only at higher doses (≥175 mg/kg-day). Adult female rats were only exposed up to 150 mg/kg-day in the subchronic study (Butenhoff et al., 2012a; van Otterdijk, 2007b) so whether these animals would exhibit the same effects at the exposure levels used in the developmental toxicity study Das et al. (2008) is unclear. Regardless, the data for relative liver weight seem to indicate that male animals are more susceptible to this effect than female animals, possibly because females have a much faster (5–6 times greater) excretion rate than males (see Section 3.1.4 for details).

Changes in absolute liver weight across all studies were generally consistent with those observed for relative liver weight. Following 10 days of dietary exposure to 0.02% (w/w) PFBA, absolute liver weights were observed to be increased 64% in male C57Bl/6 mice (Permadi et al., 1993; Permadi et al., 1992). Absolute liver weights were also increased 27% and 45% following 28 days of exposure to 30 or 150 mg/kg-day NH4+PFB, respectively (Butenhoff et al., 2012a; van Otterdijk, 2007a). No effects were observed in female rats following exposure or in male rats following a 21-day recovery. Similar to increases following 28-day exposures, liver weights were also observed to increase due to treatment in male S-D rats exposed to NH4+PFB for 90 days (Butenhoff et al., 2012a; van Otterdijk, 2007b), with absolute liver weights increased by 23%. Liver weights returned to control levels following a 21-day recovery period. As observed in the short-term study, exposure to NH4+PFB for 90 days did not increase liver weights in female rats (~3%−8% increases). In a developmental toxicity study in CD-1 mice (Das et al., 2008), exposure to NH4+PFB increased absolute liver weights in pregnant and nonpregnant P0 females at ≥175 mg/kg-day. Absolute liver weights were increased by 24% and 35% at 175 and 350 mg/kg-day, respectively, in pregnant mice, whereas absolute liver weights were increased 34% and 21% at those same doses in nonpregnant P0 females. Similar magnitudes of absolute liver weights increase (27% and 32%) also were observed in F1 animals at PND 1 at 175 and 350 mg/kg-day (Das et al., 2008). As with relative liver weights, no effect was observed in offspring at PND 10 or in pregnant P0 animals at postweaning (PND 22).

Figure 3-5 Liver-weight response to ammonium perfluorobutanoate (NH_4_^+^PFB) or perfluorobutanoic acid (PFBA) exposure (see interactive data graphic and rationale for study evaluations for liver-weight effects (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-liver-weight-effects/) in Health Assessment Workspace Collaborative [HAWC])

##### Histopathology

Histopathological examination of the livers of mice and rats across three separate gavage studies of 28-day (Butenhoff et al., 2012a; Foreman et al., 2009; van Otterdijk, 2007a) or 90-day (Butenhoff et al., 2012a; van Otterdijk, 2007b) exposure duration revealed significant, dose-dependent alterations and lesions (see Table 3-7 and Figure 3-6).

Both wild-type and hPPARα mice exposed to PFBA for 28 days developed hepatocellular hypertrophy (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-liverhistopathology-effect-size-animal/) at doses ≥35 mg/kg-day (incidences of 100% in all doses), whereas PPARα null mice did not develop hypertrophic lesions at any dose following 28-day exposures (Foreman et al., 2009). Although the incidence and severity of the hypertrophic lesions were similar between wild-type and hPPARα mice at higher doses, hPPARα mice developed more severe lesions at 35 mg/kg-day than did the wild-type mice (5/10 severe lesions vs. 0/10, respectively). Hepatocellular hypertrophy also was observed in 6/10 S-D rats exposed to 150 mg/kg-day PFBA for 28 days (Butenhoff et al., 2012a; van Otterdijk, 2007a) and 9/10 rats exposed to 30 mg/kg-day PFBA for 90 days (Butenhoff et al., 2012a; van Otterdijk, 2007b). In both cases, no lesions were observed in animals following a 21-day recovery period.

hPPARα mice were much less susceptible to the development of hepatic focal necrosis (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-liverhistopathology-effect-size-animal/) following a 28-day exposure to PFBA compared to wild-type mice. Wild-type mice developed hepatic focal necrosis (with inflammatory cell infiltration) at 35 mg/kg-day (1/10), 175 mg/kg-day (6/10) and 350 mg/kg-day (9/10), whereas focal necrosis was observed in only 1/10 (35 and 175 mg/kg-day) and 2/10 (350 mg/kg-day) hPPARα mice (Foreman et al., 2009). PPARα null mice only developed focal necrosis in the 175 mg/kg-day (1/10) and 350 mg/kg-day (2/10) dose groups. For all strains, most of the necrotic lesions were judged mild in severity. By comparison, in rats exposed to PFBA for 28 days, no increase in hepatocellular coagulative necrosis (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-liverhistopathology-effect-size-animal/) (Butenhoff et al., 2012a; van Otterdijk, 2007a) was observed. No effects on hepatocellular necrosis in rats were observed following 90-day exposures to PFBA (Butenhoff et al., 2012a; van Otterdijk, 2007b).

Following exposure to 350 mg/kg-day for 28 days, centrilobular and periportal vacuolation was observed in PPARα null and humanized mice, respectively, while no vacuolation was reported for wild-type mice (Foreman et al., 2009). Whether these effects occurred at lower doses was not mentioned. Further, no quantitative data were reported for these effects, so examining the dose-response or magnitude of effect across doses was not possible. The lack of vacuolation in wild-type animals is consistent with the lack of vacuolation in rats exposed to PFBA for 90 days (Butenhoff et al., 2012b; van Otterdijk, 2007b), where 4/10 control animals were reported to exhibit vacuolation, but incidence dropped to 1/10 in the low-dose group and no vacuolation was observed at higher doses.

All mice in all exposure groups were observed to develop hepatocellular hypertrophy (characterized by increased cytoplasmic eosinophilia, decreased glycogen content, and increased cellular volume) following dermal exposures of up to 15% v/v (Weatherly et al., 2021). Necrotic lesions were not consistently observed following dermal exposure to PFBA, although genes associated with necrosis were increased following exposure.

Although the number of studies was small, mice did seem more sensitive to development of hepatocellular lesions compared to rats, possibly owing to the observed differences in pharmacokinetics between the two species: Mice are observed to have serum excretion half-lives approximately two times longer than rats at similar exposure levels (see Section 3.1.4 and Table 3-2 for details).

Table 3-7 Incidence and severity of liver histopathological lesions due to perfluorobutanoic acid (PFBA) exposure in short-term and subchronic oral toxicity studies

Animal group (n = 10 in all groups) | Dose (mg/kg-d)
Animal group (n = 10 in all groups) | 0 | 1.2 | 6 | 30 | 35 | 150 | 175 | 350
Hypertrophy
28 d; male rats; Butenhoff et al. (2012a); van Otterdijk (2007b) | 0 | | 0 | 0 | | 6 (min)
90 d; male rats; Butenhoff et al. (2012a); van Otterdijk (2007b) | 0 | 0 | 0 | 9 (5 min, 4 mild)
28 d; PPARα wild-type male mice; Foreman et al. (2009) | 0 | | | | 10 (4 mild, 6 mod) | | 10 (1 mild, 1 mod, 8 sev) | 10 (sev)
28 d; hPPARα male mice; Foreman et al. (2009) | 0 | | | | 10 (1 mild, 4 mod, 5 sev) | | 10 (2 mod, 8 sev) | 10 (sev)
28 d; PPARα null male mice; Foreman et al. (2009) | 0 | | | | 0 | | 0 | 0
Coagulative necrosis
90 d; male rats; Butenhoff et al. (2012a); van Otterdijk (2007b) | 0 | | 0 | 0 | | 0
Focal necrosis^a^
28 d; PPARα wild-type male mice; Foreman et al. (2009) | 0 | | | | 1 (mild) | | 6 (2 min, 4 mild) | 9 (8 mild, 1 mod)
28 d; hPPARα male mice; Foreman et al. (2009) | 0 | | | | 1 (min) | | 1 (min) | 2 (min)
28 d; PPARα null male mice; Foreman et al. (2009) | 0 | | | | 0 | | 1 (min) | 2 (min)
Vacuolation
| None reported
28 d; hPPARα male mice; Foreman et al. (2009) | Periportal vacuolation reported to increase at 350 mg/kg-d, compared to controls (responses at 35 mg/kg-d or 175 mg/kg-d were not reported by study authors)
28 d; PPARα null male mice; Foreman et al. (2009) | Centrilobular vacuolation reported to increase at 350 mg/kg-d, compared to controls (responses at 35 mg/kg-d or 175 mg/kg-d were not reported by study authors)

Bolded cells indicate statistically significant changes compared to controls; shaded cells represent doses not investigated in the individual studies. Severity normalized to four points scaled as follows: min = minimal severity; mild = mild/slight severity; mod = moderate severity; sev = marked severity.

a Incidence of focal necrosis for the positive control of Wy-14,643 (a known PPARα/γ activator) was 3 total (1 minimal, 2 mild) at 50 mg/kg-d exposure.

Figure 3-6 Liver histopathology response to ammonium perfluorobutanoate (NH_4_^+^PFB) or perfluorobutanoic acid (PFBA) exposure (see interactive data graphic and rationale for study evaluation for liver histopathology effects (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-liver-histopathology-effects/) in Health Assessment Workspace Collaborative [HAWC])

A screenshot of a computer Description automatically generated

##### Serum biomarkers

Serum biomarkers (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-clinical-chemistry-28-days-effect-size-animal/) associated with altered liver function or injury including ALT, AST, ALP, total protein, albumin, and total bilirubin were not significantly changed in male or female S-D rats exposed to up to 150 mg/kg-day PFBA for 28 days (Butenhoff et al., 2012a; van Otterdijk, 2007a). However, prothrombin time (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-hematology-effect-size-animal/) (a measure of clotting time induced by the liver-produced prothrombin protein) was decreased at 150 mg/kg-day in males and at 6 and 30 mg/kg-day in females (but not at 150 mg/kg-day), although decreases were small (~5%−9% relative to control) and were reported to be within the concurrent reference range for S-D rats. Prothrombin time, however, was statistically significantly decreased (p < 0.01) in all dose groups in females after the 21-day recovery period. Some alterations in serum biomarkers (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-clinical-chemistry-90-days-effect-size-animal/) were also observed in rats exposed to PFBA for 90 days: ALP was increased 32% in male rats exposed to 30 mg/kg-day and bilirubin was decreased 21% and 13% in male and female rats (respectively) exposed to 30 mg/kg-day (Butenhoff et al., 2012a; van Otterdijk, 2007a). ALT was not statistically significantly increased by PFBA exposure in wild-type, PPARα null, or hPPARα mice (Foreman et al., 2009), although it did increase almost 3-fold at 350 mg/kg-day (20.28 U/I) compared to controls (7.39 U/I). Cholesterol levels (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-clinical-chemistry-28-days-effect-size-animal/) were significantly (p < 0.01) decreased 20% and 27% in male rats exposed to 30 and 150 mg/kg-day PFBA, respectively, for 28 days (Butenhoff et al., 2012a; van Otterdijk, 2007a). Cholesterol levels returned to control values following recovery, and no effects on cholesterol were observed in male rats exposed to PFBA for 90 days. No clear explanation exists to describe why cholesterol levels might be changed after 28, but not 90, days of PFBA exposure.

In mice exposed to PFBA dermally (up to 15% v/v), several serum biomarkers including serum cholesterol, glucose, and ALP were increased, and urea nitrogen was decreased, relative to controls (Weatherly et al., 2021). Other serum biomarkers (ALT, total protein, albumin, or globulin) were not increased due to exposure.

#### Mechanistic Evidence and Supplemental Information

The liver effects observed in the PFBA database consist of increased liver weight, increased incidence of hepatocellular hypertrophy, and (to a lesser degree) hepatocellular necrosis. Increased liver weight and hepatocellular hypertrophy can be associated with changes that are adaptive in nature (Hall et al., 2012) and not necessarily indicative of adverse effects unless observed in concordance with other clinical, pathological markers of overt liver toxicity (see PFBA Protocol; Appendix A). The IRIS PFAS Assessment Protocol (which addresses PFBA) states the panel recommendations from Hall et al. (2012) can be used to judge whether observed hepatic effects are adverse or adaptive in nature. Given that Hall et al. (2012) was focused on framing noncancer liver effects in the context of progression to liver tumors, however, the protocol further indicates that “…consultation of additional relevant information will be considered to interpret the adversity of noncancer liver effects over a lifetime exposure, taking into account that effects perceived as adaptive can progress into more severe responses and lead to cell injury.” For PFBA, the “additional relevant information” consists of multiple in vitro mechanistic studies, an in vivo study investigating PFBA-induced liver effects in wild-type humanized PPARα mice, and PPARα-null mice (Foreman), as well as evidence from other PFAS that help elucidate possible MOAs of PFBA liver toxicity.

Many of the hepatic effects caused by exposure to perfluoroalkyl acids such as PFBA have been attributed to activation of the peroxisome proliferator-activated receptor alpha (PPARα^12^) (Rosenmai et al., 2018; Bjork and Wallace, 2009; Foreman et al., 2009; Wolf et al., 2008). Due to reported cross-species differences in PPAR signaling potency and dynamics, the potential human relevance of some hepatic effects has been questioned, particularly as it relates to differences in PPARα activation and activity across species. The goal of the qualitative analysis described in this section is to evaluate the available mechanistic evidence for PFBA-induced liver effects and to assess the biological relevance of effects observed in animal models to possible effects in humans.

Although the database is smaller for PFBA than for some other PFAS, in vitro studies demonstrate that PFBA activates PPARα in both rodent and human cell lines. Studies using rodent cell lines or COS-1 cells transfected to express rodent PPARα generally report that exposure to PFBA consistently results in activation of PPARα and increased expression of PPARα-responsive genes (Rosen et al., 2013; Wolf et al., 2012; Bjork and Wallace, 2009; Wolf et al., 2008). Although PFAS generally have been shown to activate PPARα, however, shorter chain PFAS such as PFBA appear to be weak activators. For example, Bjork and Wallace (2009) showed PFBA is a weaker activator of PPARα in primary rat and human hepatocytes than is either the six-carbon PFHxA or the eight-carbon PFOA. PFBA is also one of the weakest mouse and human PPARα activators compared with other longer chain PFAS [i.e., C5−C12; Rosen et al. (2013); Wolf et al. (2012); Wolf et al. (2008)]. These studies also observed diminished effects and transcription levels in human cell lines (primary hepatocytes) or COS-1 cells transfected with human PPARα compared to mice (primary hepatocytes or transfected COS-1 cells). One study using the human hepatoma cell line HepG2 also reported activation of PPARα after exposure to PFBA for 24 hours, further demonstrating that the human PPARα can be activated by PFBA (Rosenmai et al., 2018). Interestingly, when modeling the slope of PPARα activation in human hepatoma cells for various PFAS, Rosenmai et al. (2018) observed PFBA (slope = 7.4 × 10^−3^) was a stronger activator than PFOA (slope = 4.9 × 10^−3^). Foreman et al. (2009) investigated PPARα activation in the liver of mice following in vivo exposure to PFBA. The PPARα-responsive gene CYP4A10 was activated to a greater degree in wild-type mice than in humanized mice, but acyl-CoA oxidase (ACO, active in β-oxidation and lipid metabolism) appeared to be activated to a similar magnitude in both wild-type and humanized mice. The known PPAR α/γ activator Wy-14,643 activated CYP4A10 and ACO to a similar magnitude in humanized PPARα mice compared to PFBA but to a lesser degree in wild-type mice. Neither gene was activated following exposure to PFBA or Wy-14,643 in PPARα null mice. Although the database is smaller for PFBA than for some other PFAS, in vitro studies demonstrate that PFBA activates PPARα in both rodent and human cell lines. Studies using rodent cell lines or COS-1 cells transfected to express rodent PPARα generally report that exposure to PFBA consistently results in activation of PPARα and increased expression of PPARα-responsive genes (Rosen et al., 2013; Wolf et al., 2012; Bjork and Wallace, 2009; Wolf et al., 2008). Although PFAS generally have been shown to activate PPARα, however, shorter chain PFAS such as PFBA appear to be weak activators. For example, Bjork and Wallace (2009) showed PFBA is a weaker activator of PPARα in primary rat and human hepatocytes than is either the six-carbon PFHxA or the eight-carbon PFOA. PFBA is also one of the weakest mouse and human PPARα activators compared with other longer chain PFAS [i.e., C5−C12; Rosen et al. (2013); Wolf et al. (2012); Wolf et al. (2008)]. These studies also observed diminished effects and transcription levels in human cell lines (primary hepatocytes) or COS-1 cells transfected with human PPARα compared to mice (primary hepatocytes or transfected COS-1 cells). One study using the human hepatoma cell line HepG2 also reported activation of PPARα after exposure to PFBA for 24 hours, further demonstrating that the human PPARα can be activated by PFBA (Rosenmai et al., 2018). Interestingly, when modeling the slope of PPARα activation in human hepatoma cells for various PFAS, Rosenmai et al. (2018) observed PFBA (slope = 7.4 × 10^−3^) was a stronger activator than PFOA (slope = 4.9 × 10^−3^). Foreman et al. (2009) investigated PPARα activation in the liver of mice following in vivo exposure to PFBA. The PPARα-responsive gene CYP4A10 was activated to a greater degree in wild-type mice than in humanized mice, but acyl-CoA oxidase (ACO, active in β-oxidation and lipid metabolism) appeared to be activated to a similar magnitude in both wild-type and humanized mice. The known PPAR α/γ activator Wy-14,643 activated CYP4A10 and ACO to a similar magnitude in humanized PPARα mice compared to PFBA but to a lesser degree in wild-type mice. Neither gene was activated following exposure to PFBA or Wy-14,643 in PPARα null mice.

One in vivo study Foreman et al. (2009) provided evidence that oral PFBA exposure elicits apical, toxicological effects in humanized PPARα mice. This study showed that increased liver weight and hepatocellular hypertrophy were induced following exposure to ≥35 mg/kg-day PFBA in wild-type and hPPARα mice. Although magnitude of liver-weight increases was larger for wild-type mice, the effect on hypertrophy was the same for wild-type and hPPARα mice at higher exposures. Conversely, hPPARα mice had more severe lesions at lower doses compared with wild-type mice. Increased liver weight and hypertrophy also occurred in positive controls treated with Wy-14,643.

Liver enlargement is one of the most common observations associated with chemical exposures via the oral route in laboratory animals and humans. In addition to measured increases in the mass of liver tissue, histological evaluation typically reveals isolated or multifocal areas of hepatocellular hypertrophy. The swelling of hepatocytes could include accumulation of lipid material (e.g., micro- or macrovesicular steatosis), organellar growth and proliferation (e.g., peroxisomes, endoplasmic reticulum), increased intracellular protein levels (e.g., Phase I and II enzymes), and altered regulation of gene expression (e.g., stress response, nuclear receptors) (for review see, Batt and Ferrari (1995)). Importantly, hepatocellular hypertrophy alone is morphologically indistinguishable between an adaptive or toxic response in the absence of additional indicators of cell status Williams and Iatropoulos (2002), such as reduced glutathione (GSH) levels, mitochondrial integrity, receptor-dependent or independent signal transduction pathway activity (e.g., pro-survival vs. pro-cell death balance), or redox state, for example. Although hepatocellular hypertrophy is commonly attributed to receptor-dependent organellar growth and proliferation (e.g., PPAR mediated), the milieu of pathways involved in modulating hepatocyte structural and functional response to chemicals are diverse (Williams and Iatropoulos, 2002). For example, hepatocyte swelling also has been associated with cell death processes, in particular oncosis or oncotic necrosis (Kleiner et al., 2012). Several liver diseases or conditions, such as ischemia-reperfusion injury, drug-induced liver toxicity, and partial hepatectomy, have noted oncosis (oncotic necrosis) upon cellular/tissue examination (for review see, Kass (2006); Jaeschke and Lemasters (2003)) and are not dependent on peroxisome proliferation or PPAR signaling. Rather, cellular alterations such as a transition in mitochondrial membrane permeability and caspase activation (especially Caspase-8) have been identified as key mediators or tipping points for a shift from a hypertrophic (oncotic) hepatocellular phenotype to apoptotic or primary necrotic cell death (Malhi et al., 2006; Van Cruchten and Van Den Broeck, 2002). As such, an assumption that chemical-induced hepatocellular hypertrophy is by default a distinctly proliferative/growth response associated exclusively with PPAR signaling might not be accurate.

One study investigated the activation of PPARα and pregnane X receptor (PXR) in the livers of exposed neonatal mice (Das et al., 2008). This study showed the expression of genes associated with either PPARα or PXR was not increased in the livers of neonatal male and female mice, possibly indicating that the increased liver weights in these animals were associated with a non-PPARα or PXR MOA. No other PFBA-specific studies investigated activation of other isoforms of PPAR (e.g., PPARγ) or additional pathways (e.g., constitutive androstane receptor [CAR] or pregnane X receptor [PXR]); however, evidence from human cell culture experiments involving PFOS and PFOA, two of the most heavily studied PFAS, suggest the possibility of other non-PPARα MOAs operational in liver toxicity. For example, PFOA and PFOS exposure is associated with PPARγ activation (Beggs et al., 2016; Buhrke et al., 2015), and increased mRNA levels of CAR and PXR responsive genes (Abe et al., 2017; Zhang et al., 2017). Activation of these hepatic nuclear receptors plays an important role in regulating responses to xenobiotics and in energy and nutrient homeostasis (di Masi et al., 2009). Animal studies of other PFAS also provide some evidence suggesting that nuclear receptor pathways other than PPARα might be involved in PFAS-induced liver effects. For example, two separate in vivo studies using PPARα null animal models report increases in absolute and relative liver weight (Das et al., 2017; Rosen et al., 2017) and in hepatocellular hypertrophy and lipid accumulation (Das et al., 2017) following PFHxS or PFNA exposure. Multiple in vivo studies have also evaluated activation of CAR and PXR in rodents exposed to PFDA: PFDA exposure in wild-type C57BL6/6J mice led to increased nuclear translocation of CAR and mRNA levels of CAR/PXR responsive genes [CYP2B10 and CYP3A11; Abe et al. (2017)]; these effects were not observed in CAR or PXR null mice. PFDA has also been observed to activate PXR in human HepG2 cells (Zhang et al., 2017) and increase mRNA levels of CAR/PXR-regulated genes (CYP2B6 and CYP3A4) in primary human hepatocytes (Rosen et al., 2013).

In addition to hypertrophy, Foreman et al. (2009) also observed additional histopathological effects. Hepatic focal necrosis was statistically significantly increased following exposure of wild-type mice to ≥175 mg/kg-day PFBA. Although no statistically significant increases in focal necrosis were observed at any dose in PPARα null or humanized mice, necrosis did increase slightly in the highest dose compared to controls (2/10 vs. 0/10) in both strains; that exposure to higher doses of PFBA would elicit increased necrotic effects in hPPARα or PPARα null mice is possible. Foreman et al. (2009) suggest that, given the differences in pharmacokinetics between the strains (see Section 3.1) and lower liver concentrations of PFBA in humanized and null mice, that higher levels of exposure could possibly elicit a similar phenotype in these strains. Interestingly, no statistically significant increase in focal necrosis was observed in any mouse strain treated with Wy-14,643 in this study. That PFBA exposure resulted in statistically significant increases in liver necrosis in wild-type mice, but not PPARα null mice, suggests that PPARα is required for the development of this lesion. The observation that the positive control for PPARα activation, Wy-14,643 also did not result in statistically significant increase in this lesion (in this study) further supports that a PPARα-independent, complementary, or multifaceted MOA could be active in the observed liver toxicity. Supporting this conclusion is the observation that centrilobular and periportal vacuolation (i.e., lipid accumulation) was increased compared with controls in PPARα null and humanized mice after exposure to 350 mg/kg-day PFBA, with greater vacuolation in PPARα null mice than in humanized mice. Vacuolation was not reported in wild-type mice, and results for the vacuolation endpoints were provided only for the control and high-dose groups for the PPARα null and hPPARα mice. This result is consistent with Das et al. (2017) reported PFAS increased accumulation and oxidation of lipids in the liver of exposed mice, with accumulation occurring faster than oxidation. Thus, although vacuolation occurs in humanized PPARα mice, oxidation is also induced (as evidenced by the upregulation of ACO), limiting lipid accumulation to a degree. In PPARα null mice, however, accumulation of lipids in the liver of exposed animals must be occurring through a PPARα-independent mechanism. Thus, PFBA appears to result in increased lipid accumulation in the liver via a PPARα-independent mechanism, and although humanized mice do exhibit an increase in β-oxidation via ACO upregulation, this increase in lipid catabolism is not sufficient to overcome the increased lipid deposition in the liver.

The observation of increased liver weight, increased incidence of hepatocellular hypertrophy, vacuolation, and necrosis in wild-type and humanized PPARα mice is important when considered in the context of the recommendations of the Hall et al. (2012) paper. In interpreting “histological changes caused by an increase in liver weight”—exactly the situation observed in PFBA-exposed hPPARα mice in Foreman et al. (2009)—Hall et al. (2012) suggests that coincident histological evidence of liver injury/damage can be used to support the conclusion that the liver weight increases/histological changes (i.e., hypertrophy) are adverse. Among the histological changes that Hall et al. (2012) identifies as sufficient supporting evidence is necrosis and steatotic vacuolar degeneration, with the study authors further differentiating between macrovesicular vacuolation (considered nonadverse) and microvesicular vacuolation. Microvesicular vacuolation is described by the presence of hepatocytes partially or completely filled with multiple small vacuoles without displacement of the nucleus (Kleiner and Makhlouf, 2016). This pattern of vacuolation is precisely what Foreman et al. (2009) observed in hPPARα mice exposed to PFBA. Additionally, focal necrosis is observed in wild-type mice in Foreman et al. (2009). Thus, according to the Hall recommendations, observation of liver weight increases, hypertrophy, microvesicular vacuolation, and necrosis across wild-type and hPPARα mice is consistent with a determination that these interconnected PFBA-induced liver effects meet the criteria for adversity.

Accumulation of lipids in the liver is an apical key event (decreased fatty acid efflux resulting in lipid accumulation) leading to hepatic steatosis (Angrish et al., 2016; Kaiser et al., 2012) and has been observed in animal toxicological studies following exposure to numerous environmental agents that ultimately cause steatosis (Joshi-Barve et al., 2015; Wahlang et al., 2013). Sustained steatosis can progress to steatohepatitis and other adverse liver diseases such as fibrosis and cirrhosis (Angrish et al., 2016). Therefore, that vacuolation occurring in null PPARα mice indicates a PPARα-independent mechanism for lipid accumulation in the liver, possibly as a precursor to more severe forms of liver injury. The occurrence of vacuolation in humanized mice further supports the human relevance of the observed hepatic toxicity.

Disrupted lipid metabolism due to PFBA exposure is supported by the findings of a dermal toxicity study Weatherly et al. (2021) that observed significant upregulation of genes associated with steatosis (Cd36, Fasn, Lpl, Scd1), cholestasis (Abcd4, Abcc2, Abcc3), and phospholipidosis (Fabp1, Hpn, Lss).

Overall, evidence specific to PFBA and from other potentially relevant PFAS provides support for both PPARα dependent and independent pathway contributions to hepatic toxicity, and further, that activation of humanized PPARα by PFBA can likewise result in hepatic effects of concern. Additionally, application of the recommendations from Hall et al. (2012) Additionally, application of the recommendations from Hall et al. (2012) clearly supports the conclusion that the multiple and interconnected effects observed in the livers of exposed animals meet the criteria for adversity.

#### Evidence Integration Summary

No association between PFBA and circulating levels of multiple serum biomarkers of hepatic injury were observed in the only available, medium confidence epidemiological study with reduced sensitivity (Nian et al., 2019b). These null findings from a single study with low sensitivity did not influence the evidence integration judgments, providing indeterminate evidence.

Hepatic effects associated with oral exposures to PFBA have been consistently observed in high or medium confidence short-term and subchronic oral studies in adult mice or rats of both sexes (Butenhoff et al., 2012a; Foreman et al., 2009; van Otterdijk, 2007a, b; Permadi et al., 1993; Permadi et al., 1992) and in an oral developmental toxicity study in mice (Das et al., 2008). Although there are hepatic effects observed in a single dermal toxicity study Weatherly et al. (2021), concerns over characterizing how dermal exposures relate to oral exposures preclude the use of this study in evidence synthesis judgments. Overall, changes in liver weights and histopathology (hepatocellular hypertrophy) were consistently observed across two species, with effects occurring in male adult rats and mice, female pregnant or nonpregnant adult mice, and in male and female neonatal mice. In particular, increases in liver weight and hepatocellular hypertrophy incidence occurred at similar dose levels across species, occurred at multiple doses, and appeared to be dose related (i.e., increasing magnitude of effect with increasing dose), as can be seen in this interactive graphic (https://hawc.epa.gov/summary/data-pivot/assessment/100500073/PFBA-Liver-Histopathology-and-Liver-Weight-Effects/) on HAWC. Although uncertainties remain, given the consistency, coherence, and inferred adversity (see below) of these findings, there is moderate animal evidence for hepatic effects of PFBA exposure.

Increased liver weights were consistently observed in male, but not female, adult rats following 28- or 90-day exposures (Butenhoff et al., 2012a; van Otterdijk, 2007a, b) and in male wild-type and hPPARα mice, pregnant and nonpregnant female mice, and neonatal male and female mice on PND 1 (Foreman et al., 2009; Das et al., 2008; Permadi et al., 1993; Permadi et al., 1992). For male rodents, the doses at which effects occurred did not differ appreciably across species, but wild-type PPARα mice seemed to exhibit greater magnitudes of effect vs. humanized PPARα mice or rats. As noted above, female pregnant and nonpregnant mice, along with their offspring, exhibited effects only at higher doses compared with adult male rats and mice, possibly relating to the observation that female rodents eliminate PFBA much more rapidly than males (see Section 3.1.4).

Liver histopathology was also consistently observed across PFBA studies (Butenhoff et al., 2012a; Foreman et al., 2009; van Otterdijk, 2007a, b), although differences in the type or severity of lesions differed somewhat across species and durations of exposure. Wild-type and hPPARα mice were both observed to develop statistically significantly increased hepatocellular hypertrophy following 28 days of oral exposure to PFBA, whereas only wild-type mice developed statistically significantly increased hepatic focal necrosis (Foreman et al., 2009). PPARα null mice were not observed to develop statistically significant increases in either of these lesions in response to exposure. Adult male rats also were observed to develop hepatocellular hypertrophy, but not coagulative necrosis, following 28 or 90 days of exposure (Butenhoff et al., 2012a; van Otterdijk, 2007a, b). Again, differences in pharmacokinetics might explain somewhat the differences in lesion incidence across species, with rats eliminating PFBA much more rapidly than mice. Interestingly, PPARα null and hPPARα mice were observed to develop centrilobular and periportal vacuolation, whereas wild-type mice did not. This possibly indicates the accumulation of lipids within the liver. Increased liver weights were concurrently observed at all doses with hepatocellular hypertrophy in wild-type and hPPARα mice following short-term exposure (Foreman et al., 2009). In wild-type mice, however, liver weight increases occurred at lower doses than did focal necrosis in the same study Foreman et al. (2009) although focal necrosis was not observed in hPPARα mice in the presence of liver weight changes at any dose. In male rats, changes in liver weight occurred at lower doses than hepatocellular hypertrophy following 28-day exposures, whereas both effects were observed at the same dose following 90-day exposures (Butenhoff et al., 2012a; van Otterdijk, 2007a, b).

Changes in serum biomarkers of liver function or injury were not consistently observed across exposure durations or concurrently with hepatocellular lesions. In the 28-day study in rats, prothrombin time alterations were observed only at 150 mg/kg-day; no statistically significant changes in ALT, AST, or ALP were observed. Although increased ALP and increased hepatocellular hypertrophy were both observed in male rats exposed to 30 mg/kg-day for 90 days in the subchronic study, no concurrent increase in ALT and AST was observed at this exposure level. Further, the observed decreased bilirubin is inconsistent with what would be expected as a marker of liver injury (i.e., an increase in bilirubin); therefore, this observation is of unclear toxicological significance as a marker of liver injury. Lastly, cholesterol levels were decreased in a dose-dependent manner following the 28-day, but not the 90-day, exposure. Although ALT was also not statistically significantly increased in wild-type, hPPRAα, or PPARα mice following exposure to PFBA, ALT was increased almost 3-fold in PPARα null mice in the high dose group (350 mg/kg-day). As a whole, the various clinical chemistry endpoints, as measurements of liver toxicity, were incoherent across some endpoints and durations of exposure. Thus, these data (i.e., on serum biomarkers of liver function) were considered too uncertain and not influential to the overall evidence integration judgments (i.e., the coherent, consistent, and biologically plausible liver weight and histopathology endpoints were strong enough on their own to support the evidence integration judgements).

One characteristic of the evidence base for PFBA is the sparsity of chemical-specific mechanistic data to inform the human relevance of the observed increases in liver weight and hypertrophic lesions in rats and mice. In the one study that does provide chemical-specific information, Exposure of wild-type and hPPARα mice to PFBA increased both liver weights and hepatocellular hypertrophy. Only wild-type mice were observed to have statistically significantly increased focal necrosis following exposure, possibly indicating that activation of PPARα was a necessary step in the MOA for developing this lesion. Hepatic focal necrosis, however, was not statistically significantly increased in any group (wild-type, hPPARα, or PPARα null mice) exposed to the positive control (the PPARα/γ activator Wy-14,643). Further, increased vacuolation was reported only in PPARα-null and hPPARα mice, an observation consistent with in vivo evidence for longer chain PFAS (Das et al., 2017). This observation (increased vacuolation) in PPARα-null and humanized mice indicates that lipid accumulation in the liver occurs, at least in part, through a PPARα-independent mechanism, and that either the lack, or attenuated activity, of PPARα-induced lipid catabolism is not sufficient to overcome the increased accumulation. This strongly suggests a complementary or multifaceted MOA for development of PFBA-induced hepatic effects. Indeed, based on evidence from other PFAS chemicals, non-PPARα mechanisms relevant to hepatic effects are apparent. In vivo and in vitro studies of PFOA, PFOS, PFDA, and PFNA demonstrate that PFAS exposure can activate PPARγ, CAR, and PXR (Abe et al., 2017; Das et al., 2017; Zhang et al., 2017; Beggs et al., 2016; Buhrke et al., 2015; Rosen et al., 2013) and that activation of these receptors results in the hepatic effects observed in PPARα null mice.

Thus, multiple lines of evidence, taken as a whole, indicate that the liver toxicity observed in rodents due to PFBA exposure is likely adverse, relevant to humans, and dependent on multiple biological pathways (i.e., both PPARα-dependent and independent pathways). Even considering a PPARα-only MOA, human PPARα is observed to be activated by PFBA exposure in vitro, and evidence in humanized PPARα mice (increased liver weight and increased hepatocellular hypertrophy, which is observed to be more severe than that in wild-type mice) indicates the PPARα-mediated components of the undefined MOA(s) appear relevant to human toxicity, given the effects are observed in animals with human PPARα receptors. Further, the existing evidence base also supports the operation of PPARα-independent pathways for other hepatotoxic effects, given the direct observation of increased vacuolation in PPARα null mice in response to PFBA exposure, an observation also occurring in humanized PPARα mice. Even in the absence of PPARα activity, hepatic toxicity occurs that is possibly the precursor to more clearly adverse liver disease (e.g., steatohepatitis, fibrosis, and cirrhosis). Thus, although there is uncertainty in relating the sensitivity of hepatic changes observed in rodents to humans given the generally decreased sensitivity of human responses to PPARα agonism, evidence from PFBA studies and studies on other PFAS indicates that PPARα alone cannot be identified as the exclusive MOA for PFBA-induced liver effects. Lastly, independent of conclusions regarding PPARα as the MOA, consideration of the recommendations from Hall et al. (2012) also support a determination that the observed hepatic effects in rodents are relevant to humans. Hall et al. (2012) indicates coincident histological evidence of liver injury/damage can be used to support the conclusion that liver weight/hypertrophic effects are adverse. That PFBA induces a constellation of effects in the liver, including increased liver weight, hypertrophy, vacuolation, and necrosis is clear from the in vivo evidence in rodents. Therefore, according to Hall et al. (2012), these coincident effects are consistent with the conclusion that PFBA-induced liver effects in rodents meet the criteria for adversity.

The available animal evidence for effects on the liver includes multiple high and medium confidence studies with consistent effects on liver weight and, separately, histopathology across multiple species, sexes, exposure durations, and study designs (e.g., exposures during pregnancy); it exhibits coherence between the effects on liver weights and histopathology and a clear biological gradient (increasing effect with increasing dose); and the evidence is interpreted to be relevant to humans. Taken together, the available evidence indicates that PFBA exposure is likely to cause hepatic toxicity in humans (see Table 3-8), given relevant exposure circumstances. This judgment is based primarily on a series of short-term, subchronic, and developmental studies in rats and mice, generally exhibiting effects at PFBA exposure levels ≥30 mg/kg-day.

Table 3-8 Evidence profile table for hepatic effects

Evidence Stream Summary and Interpretation | | | | | Evidence Integration Summary Judgment
Evidence from studies of exposed humans (see Section 3.2.2: Human Studies) | | | | | ⊕⊕⊙; Evidence indicates (likely); Primary basis:; Three high and one medium confidence studies in male adult rats and mice and maternal and neonatal mice (short-term, subchronic, and gestational exposures) at ≥30 mg/kg-d PFHxA; Human relevance:; Effects in rats are considered relevant to humans (see Section 3.2.2: Mechanistic Evidence and Supplemental Information); Cross-stream coherence:; N/A (human evidence indeterminate); Susceptible populations and lifestages:; None identified, although those with preexisting liver disease could be at greater risk; Other inferences: the MOA for liver effects is not fully established, although available evidence indicates that multiple pathways are likely involved
Studies, outcomes, and confidence | Summary of key findings | Factors that increase certainty | Factors that decrease certainty | Judgments and rationale
Serum Biomarkers; 1 medium confidence study;; 1 low confidence study | - No association between PFBA and liver biomarkers or blood lipids in studies with poor sensitivity | - No factors noted | - No factors noted | ⊙⊙⊙; Indeterminate
Evidence from in vivo animal studies (see Section 3.2.2: Animal Studies)
Studies, outcomes, and confidence | Summary of key findings | Factors that increase certainty | Factors that decrease certainty | Judgments and rationale
Organ Weight; 4 high, 2 medium, and 1 low confidence studies in adult rats and maternal and neonatal mice:; - 14-d (×3); - 28-d (×2); - 90-d; - Gestational | - Increased liver weight observed in:; ○ male adult rats at ≥30 mg/kg-d; ○ female mice and PND1 neonates at ≥175 mg/kg-d; ○ male wild-type PPARα and hPPARα mice at ≥35 mg/kg-d (no effects in PPARα null mice); - Reduced effects in female rats could be attributable to pharmacokinetics | - Consistent increases, across most studies (one null study); - Dose-response in most studies (one null study); - Coherence with histopathology in male rats and mice (especially at high dose); - Magnitude of effect, up to 112%; - High and medium confidence studies | - No factors noted | ⊕⊕⊙; Moderate; Findings were considered adverse (as determined using Hall et al. (2012) criteria (see Section 3.2.2: Mechanistic Evidence and Supplemental Information), consistent, dose dependent, and biologically coherent across multiple measures of hepatic toxicity (i.e., liver weight and histopathological changes). PPARα-dependence appears likely for some effects (focal necrosis) but not others (vacuolation) Findings were considered adverse (as determined using Hall et al. (2012) criteria (see Section 3.2.2: Mechanistic Evidence and Supplemental Information), consistent, dose dependent, and biologically coherent across multiple measures of hepatic toxicity (i.e., liver weight and histopathological changes). PPARα-dependence appears likely for some effects (focal necrosis) but not others (vacuolation)
Histopathology; 2 high and 1 medium confidence studies in adult rats and mice:; - 28-d (×2); - 90-d | - Hepatocellular hypertrophy observed in:; ○ male adult rats at 30 mg/kg-d (subchronic); ○ male wild-type PPARα and hPPARα mice at ≥35 mg/kg-d (short-term); - Focal necrosis observed in male wild-type PPARα mice exposed to ≥175 mg/kg-d (short-term); - Vacuolation observed in male PPARα-null and hPPARα mice at 350 mg/kg-day (short-term); - Reduced effects in female rats could be attributable to pharmacokinetics | - Consistent cellular hypertrophy or focal necrosis across studies and species; - Coherence with liver weight effects (especially at high doses); - Dose-response; - High and medium confidence studies | - No factors noted
Serum Biomarkers; 2 high confidence studies in adult rats:; - 28-d; - 90-d | - Increased ALP and decreased bilirubin in male or male and female rats, respectively, at 30 mg/kg-d | - High confidence studies | - Incoherent observations (e.g., increased ALP but with no clear increases in ALT or AST, and bilirubin decreased not increased as expected)
Mechanistic evidence and supplemental information (see subsection above)
Biological events or pathways | Summary of key findings, interpretation, and limitations | | | Evidence stream judgment
Molecular Initiating Events—PPARα | Key findings and interpretation:; - In vitro increased expression of PPARα-responsive genes in primary rata and human hepatocytes and cells transfected with rat or human PPARα.; - In vivo increased expression of PPARα-responsive genes in wild-type and hPPARα mice.; Limitations: small database investigating PPARα activation, some inconsistencies regarding the strength of activation or interspecies differences. | | | Overall, studies in rodent and human in vitro and in vivo models suggest that PFBA induces hepatic effects, at least in part, through PPARα. The evidence also suggests a role for PPARα-independent pathways in the MOA for noncancer liver effects of PFBA.
Molecular Initiating Events—Other Pathways | Key findings and interpretation:; - Indirect evidence of alternative pathways following observation of effects in humanized PPARα and PPARα null mice exposed to PFBA.; - Direct evidence from other PFAS (PFOA, PFOS, PFDA, PFHxA, PFHxS) that multiple non-PPARα pathways (PPARγ, CAR, PXR) activated following exposure.; Limitations: No PFBA-specific in vitro data; only one in vivo study providing indirect evidence.
Organ Level Effects | Key findings and interpretation:; - Observation of increased liver weight and increased hepatocellular hypertrophy/vacuolation in humanized PPARα mice.; - Concurrent observation that a known PPARα/γ activator (Wy-14,643) did not elicit the same statistically significant increased effects (focal necrosis) as PFBA exposure in wild-type mice.; Limitations: Only one in vivo study.

### 3.2.3 Developmental Effects

This section describes studies of PFBA exposure and potential early life effects or developmental delays and effects attributable to developmental exposure. The latter includes all studies where exposure is limited to gestation or early life. As such, this section has some overlap with evidence synthesis and integration summaries for other health systems where studies evaluated the effects of developmental exposure (see Sections 3.2.2 and 3.2.4 on potential “Hepatic Effects” and “Reproductive Effects,” respectively). Synthesis descriptions of studies across sections can vary in detail, depending on the impact the data have on summarizing the evidence relevant to that hazard; typically, earlier hazard sections will include a more detailed discussion that is then cited in later sections.

#### Human Studies

The one epidemiological study that investigated developmental effects (birth weight, gestational age) Li et al. (2017a) was cross-sectional study based on umbilical cord PFBA exposure deemed low confidence primarily due to concerns over participant selection and exposure measurement. Li et al. (2017a) reported a mean birth weight deficit of −46 grams (95%CI: −111, 19) in the overall population per each unit (ng/mL) PFBA increase; this was driven by the association in boys (−86 grams; 95%CI: −180, 9) as the results were null in girls. The exposure range in this study, however, is quite small and a one-unit increase is beyond the bounds of the exposure range in this population. Thus, when expressed on an IQR unit change, they reported small birth weight deficits (−4 grams (95%CI: −10, 2) per each PFBA IQR unit change (0.09 ng/mL) and in boys (−8 grams; 95%CI: −16, 1). No association was observed with gestational age in weeks.

#### Animal Studies

A standardized suite of potential developmental effects was evaluated in one high confidence developmental toxicity study in mice (Das et al., 2008). Some outcome-specific considerations for study evaluations were influential on the overall study rating for developmental effects, but none of these individual domain-specific considerations were judged deficient, and the Das et al. (2008) study considered further in this section was rated as high confidence (see Figure 3-7). Endpoints evaluated in the study included time to eye opening, full litter resorption, postnatal survival, vaginal opening, preputial separation, body weights, and morphological evaluations (see Table 3-9 and Figure 3-8).

Figure 3-7 Evaluation results for animal studies assessing developmental effects of perfluorobutanoic acid (PFBA) exposure (see interactive data graphic for rating rationales (https://hawcprd.epa.gov/summary/visual/100500269/))

Oral exposure via gavage from GD 1 to 17 of CD-1 mice (male and female offspring were evaluated) to NH_4_^+^PFB resulted in delayed eye opening (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-developmental-effect-size-animal/) by 1.1, 1.4, and 1.5 days compared to controls at 30, 175, and 350 mg/kg-day, respectively (Das et al., 2008). Significantly increased full litter resorptions (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-full-litter-resorptions-effect-size-animal/) also occurred at 350 mg/kg-day (28% vs. 7% in controls), although no effects were observed on the number of implants or live fetuses. Additionally, although not statistically significant, postnatal survival was consistently reduced at PNDs 7, 14, and 21 by approximately 5%. The male and female reproductive developmental landmarks (preputial separation and vaginal opening, respectively) were delayed. Preputial separation (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-developmental-effect-size-animal/) was delayed by 2.3 days at 350 mg/kg-day although vaginal opening (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-developmental-effect-size-animal/) was delayed 3.3 and 3.6 days (175 and 350 mg/kg-day, respectively). No changes were observed in neonatal or postweaning body weight (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-fetal-weight-effect-size-animal/). Anatomical changes were observed (renal dilation, fetal hydronephrosis, and absent testis) but were randomly distributed among the treatment groups, including controls, and thus were not attributable to PFBA exposure.

Table 3-9 Developmental effects observed following perfluorobutanoic acid (PFBA) exposure in a developmental toxicity study

Animal group | Dose (mg/kg-d)
Animal group | 0 | 35 | 175 | 350
Full-litter resorptions; pregnant P_0_ female CD-1 mice on GD 18; Das et al. (2008) | 2/29 | 1/29 | 4/28 | 8/29
Survival to PND 1 (%); F_1_ male and female CD-1 mice on PND 1; Das et al. (2008) | 91.7 ± 2.1 | 90.2 ± 2.4 | 92.9 ± 1.6 | 87.9 ± 2.6
Survival to PND 7 (%); F_1_ male and female CD-1 mice on PND 7; Das et al. (2008) | 90.9 ± 2.3 | 90.0 ± 2.3 | 90.0 ± 3.1 | 86.4 ± 2.7
Survival to PND 14 (%); F_1_ male and female CD-1 mice on PND 14; Das et al. (2008) | 90.9 ± 2.3 | 89.7 ± 2.4 | 89.6 ± 3.2 | 85.7 ± 3.0
Survival to PND 21 (%); F_1_ male and female CD-1 mice on PND 21; Das et al. (2008) | 90.9 ± 2.3 | 88.7 ± 2.4 | 89.6 ± 3.2 | 85.7 ± 3.0
Delayed eye opening (d); F_1_ male and female CD-1 mice; Das et al. (2008) | 16.28 ± 1.19 | 17.38 ± 0.79 | 17.69 ± 0.68 | 17.8 ± 0.83
Delayed vaginal opening (d); F_1_ female CD-1 mice; Das et al. (2008) | 31.25 ± 2.62 | 33.71 ± 2.59 | 34.57 ± 2.59 | 34.92 ± 2.23
Delayed preputial separation (d); F_1_ male CD-1 mice; Das et al. (2008) | 29.55 ± 1.14 | 30.21 ± 1.99 | 30.56 ± 1.84 | 31.88 ± 1.72

Bolded cells indicate statistically significant changes compared to controls.

Figure 3-8 Pre- and postnatal developmental responses to gestational ammonium perfluorobutanoate (NH_4_^+^PFB) exposure (see interactive data graphic and rationale for study evaluations for developmental effects (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-developmental-effects/) in Health Assessment Workspace Collaborative [HAWC])

#### Evidence Integration Summary

One low confidence human study reported lower birth weight in boys with higher PFBA exposure. No association was observed with gestational age. The lack of additional studies with lower risk of bias reduces the interpretability of these findings. Overall, the evidence on potential developmental effects from studies of humans exposed to PFBA was indeterminate.

Coherent effects on developmental maturation were observed in one high confidence study in mice Das et al. (2008) following in utero exposure to PFBA. The developmental effects of PFBA exposure in this study included delayed eye opening, full-litter resorption, decreased survival, fetal absent testis, and delays in vaginal opening and preputial separation, although pup growth and body weight were unaffected. These effects indicate that PFBA appears to disrupt the normal gestational and postnatal development of exposed fetuses. One factor increasing the strength of evidence is that effects on the developing offspring (e.g., delayed eye opening, delays in the development of the male and female reproductive systems) are seen following exposure to other PFAS, most notably the structurally related compound perfluorobutane sulfonate (U.S. EPA, 2018b) but other, longer chain PFAS as well. Following exposure to ≥200 mg/kg-day PFBS (U.S. EPA, 2018b) or 5 mg/kg-day perfluorooctanoic acid [PFOA; Lau et al. (2006)] or perfluorooctane sulfonate [PFOS; Lau et al. (2004)], similar delays in eye opening (~1.5 days) were observed in mice. Similarly, following exposure to ≥200 mg/kg-day PFBS, time to vaginal opening was increased by >3 days (Feng et al., 2017) and time to vaginal patency was increased ~3 days in mice exposed to 20 mg/kg-day PFOA (Lau et al., 2006) and ~2 days in rats exposed to 30 mg/kg-day PFOA (Butenhoff et al., 2004). Time to reach reproductive milestones was also altered in male rodents exposed to PFOA: preputial separation accelerated 2–4 days in mice exposed to doses up to 10 mg/kg-day and delayed ~1.5 days in mice exposed to 20 mg/kg-day (Lau et al., 2006). In rats exposed to 30 mg/kg-day PFOA, preputial separation was delayed ~3.5 days (Butenhoff et al., 2004). Thus, qualitatively, a consistent pattern of altered reproductive milestones is observed following exposure to other PFAS, including the structurally related PFBS, increasing certainty in the similar findings available for PFBA.

The onset of puberty in humans is driven by surges in the levels of estrogen in females and testosterone in males, so the timing of puberty can be altered by exposure to endocrine disrupting chemicals that mimic or antagonize these hormones. In female rodents, pubertal markers include vaginal opening (indicative of the first ovulation in rats, but not mice) and the subsequent first estrus and onset of regular estrous cyclicity (rats and mice) (Prevot, 2014). Since vaginal opening isn’t indicative of first ovulation in mice, the delayed vaginal opening in mice reported by Das et al. (2008), not a direct correlate to puberty in humans. However, it is assuredly a marker of sexual and/or reproductive development. As the EPA’s Reproductive Guidelines (U.S. EPA, 1996) state that both accelerations and delays in the timing of puberty should be considered adverse, it is reasonable to extend this conclusion to developmental milestones that are more broadly indicative of sexual and/or reproductive developmental, Further, the absence of effects on body weight in PFBA-exposed offspring or maternal toxicity strengthens the confidence that the observed developmental delays are biologically significant, adverse effects. Taken together, the available animal studies provided moderate evidence of potential developmental effects.

Data gaps in the developmental toxicity database include a lack of information on the thyroid and nervous system following gestational exposure. Given that PFBS alters thyroid hormone levels following gestational exposure and that PFBA induces changes in thyroid hormone levels in exposed adult animals, PFBA also might alter normal thyroid hormone action in the developing fetus. As both PFBA and PFBS evidence bases lack studies on developmental neurotoxicity, a potential consequence of altered thyroid hormone action during development, this represents an important unknown.

Thus, considering the coherent suite of developmental effects, primarily developmental delays, observed following PFBA exposure in one high confidence study, and similar effects observed following exposure to multiple other PFAS (including the structurally similar PFBS), the evidence indicates PFBA exposure is likely to cause adverse developmental effects in humans (see Table 3-10), given relevant exposure circumstances. The basis for this judgment is a single high confidence gestational exposure study in mice, with multiple adverse effects occurring at PFBA exposure levels ≥175 mg/kg-day (with delays in eye opening occurring at ≥35 mg/kg-day). Notably, even in the absence of evidence informing potential similarities of effects between PFBA and other PFAS regarding gestational thyroid hormone action, the available PFBA-specific developmental effects alone support this judgment.

Table 3-10 Evidence profile table for developmental effects

Evidence Stream Summary and Interpretation | | | | | Evidence Integration Summary Judgment
Evidence from studies of exposed humans (see Section 3.2.3: Human Studies) | | | | | ⊕⊕⊙; Evidence indicates (likely); Primary basis:; One high confidence gestational study in mice, with effects observed at ≥35 mg/kg-d PFBA; Human relevance:; In the absence of evidence to the contrary, the developmental effects observed in mice are considered relevant to humans based on conserved biological processes; Cross-stream coherence:; N/A (human evidence indeterminate); Susceptible populations and lifestages:; Pregnancy and early life; Other inferences:; PFBA-induced developmental effects are consistent with effects seen for other PFAS (see Section 3.2.3: Evidence Integration Summary
Studies, outcomes, and confidence | Summary of key findings | Factors that increase certainty | Factors that decrease certainty | Judgments and rationale
Birth Weight; 1 low confidence study | - Birth weight deficit with higher PFBA exposure in boys (nonstatistically significant) | - No factors noted | - Low confidence study; - Imprecision | ⊙⊙⊙; Indeterminate
Evidence from in vivo animal studies (see Section 3.2.3: Animal Studies)
Studies, outcomes, and confidence | Summary of key findings | Factors that increase certainty | Factors that decrease certainty | Judgments and rationale
Developmental Milestones; 1 high confidence gestational study in mice | - Dose-dependent delays in developmental milestones in:; ○ Eye opening in males and females at ≥35 mg/kg-d; ○ Preputial separation in males at 350 mg/kg-d; ○ Vaginal opening in females at 175 and 350 mg/kg-d; - Increased full litter resorption at 350 mg/kg-d; - No effects on pup weight | - Dose-response gradient; - Coherence across developmental milestones; - Magnitude of effect, up to 12% increase in time to milestone and 4-fold increase in full litter resorptions; - High confidence study | - No factors noted | ⊕⊕⊙; Moderate; Coherent delays in developmental milestones, with multiple alterations observed at ≥35 mg/kg-d

### 3.2.4 Reproductive Effects

#### Human Studies

One low confidence (https://hawcprd.epa.gov/rob/study/100517937/) cross-sectional study Song et al. (2018) examined the association between PFBA exposure and semen parameters. No evidence of an association between PFBA exposure and decreased semen quality was found (correlation coefficients were −0.03 for semen concentration and 0.2 for progressive motility), although issues were noted during study evaluation regarding the ability of this study to detect an effect due to the small sample size (n = 58) and risk of outcome misclassification, which makes the null finding difficult to interpret. Other study deficiencies including the potential for selection bias and confounding were noted in the study evaluation, but the direction of these biases is unknown.

#### Animal Studies

Two high confidence studies reported in three publications from the same research group Butenhoff et al. (2012a); van Otterdijk (2007a, 2007b) evaluated the effects of PFBA exposure on reproductive organ weights in rats (see Figure 3-9). In addition, one high confidence developmental toxicity study Das et al. (2008) reported several delays in reproductive system development (e.g., vaginal opening, preputial separation) after gestational exposure in mice. These latter results are synthesized and integrated with other studies examining developmental outcomes (see Section 3.2.3) given the apparent coherence of findings of developmental delays after PFBA exposure and the general lack of other studies or effects on reproduction, including an absence of studies on functional measures (see discussion below).

##### Organ weight

Short-term exposure (28 d) to PFBA in male S-D rats increased absolute epididymis weight (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-reproductive-organ-weight-effect-size-animal/) (note: absolute organ weights are typically preferred for these reproductive organ measures) 10% compared to controls, but only at the lowest dose [6 mg/kg-day; Butenhoff et al. (2012a); van Otterdijk (2007a)]. In a separate cohort, this effect was not observed following a 3-week recovery period (at 49 days) from exposure at any dose (6, 30, or 150 mg/kg-day). Changes in absolute or relative testis weight (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-reproductive-organ-weight-effect-size-animal/) were not observed in rats following either 28 days of exposure or during the recovery period. Similarly, no changes in absolute or relative ovary weight (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-reproductive-organ-weight-effect-size-animal/) were observed in rats following short-term (28 days) PFBA exposure and none arose during the recovery period (Butenhoff et al., 2012a; van Otterdijk, 2007a).

Figure 3-9 Reproductive responses to ammonium perfluorobutanoate (NH_4_^+^PFB) exposure (see interactive data graphic and rationale for study evaluations for reproductive effects (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-reproductive-effects/) in Health Assessment Workspace Collaborative [HAWC])

#### Evidence Integration Summary

The database of studies examining the potential for PFBA exposure to elicit effects on reproductive parameters is limited to one human and one animal study. There is evidence for delayed development of the reproductive system (i.e., delayed vaginal opening and preputial separation) following gestational PFBA exposure (Das et al., 2008). These latter results are synthesized and integrated in the developmental effects section (see Section 3.2.3) where the human relevance of delayed development of the reproductive system observed in mice are outlined and not discussed further in this section.

In the only available human study (a low confidence study), no association was observed between semen quality and PFBA exposure. Null findings in a single study with low sensitivity (biased toward the null) are not interpreted to influence the evidence integration judgments, and thus the human evidence was indeterminate.

The available animal evidence is sparse, limited to evaluations of reproductive organ-weight measurements in a high confidence short-term experiment reported in three publications from the same research group (Butenhoff et al., 2012a; van Otterdijk, 2007a, b). Specifically, the authors evaluated reproductive organ weights in a cohort of rats immediately after exposures ended and another cohort 21 days postexposure, both of which were largely null. Given the limited interpretability of these data, the animal evidence was indeterminate.

Given the sparsity of evidence on potential reproductive effects, the relative insensitivity of the outcome measures (organ weights) in animals, and the largely null findings, there is inadequate evidence to determine whether PFBA exposure has the potential to cause reproductive effects in humans (other than the developmental delays discussed in Section 3.2.3; see Table 3-11). This determination is consistent with the lack of convincing evidence for reproductive effects for several other PFAS, including Gen X, PFOA, PFOS, and PFBS (U.S. EPA, 2021a, 2018b, 2016a, b) and (U.S. EPA, 2021b).

Table 3-11 Evidence profile table for reproductive effects

Evidence Stream Summary and Interpretation | | | | | Evidence Integration Summary Judgment
Evidence from studies of exposed humans (see Section 3.2.4: Human Studies) | | | | | ⊙⊙⊙; Insufficient Evidence; Primary basis:; One high confidence study in rats; Human relevance:; Organ weight changes in rats are considered relevant to humans in the absence of evidence to the contrary; Cross-stream coherence:; N/A (human evidence indeterminate); Susceptible populations and lifestages:; None identified
Studies, outcomes, and confidence | Summary of key findings | Factors that increase certainty | Factors that decrease certainty | Judgments and rationale
Birth Weight; 1 low confidence study | - No association between PFBA exposure and semen quality | - No factors noted | - Low confidence study | ⊙⊙⊙; Indeterminate
Evidence from in vivo animal studies (see Section 3.2.4: Animal Studies)
Studies, outcomes, and confidence | Summary of key findings | Factors that increase certainty | Factors that decrease certainty | Judgments and rationale
Organ weights; 1 high confidence 28-d study in rats | - Increased epidydimal weight in rats at 6 mg/kg-d but not higher doses; - No changes in testis or ovary weights | - No factors noted | - Lack of dose-response; - Lack of coherence across reproductive organ weights | ⊙⊙⊙; Indeterminate; Largely null findings in in the only available study that examined reproductive organ weights

### 3.2.5 Other Noncancer Health Effects

In addition to the potential health effects outlined above, some epidemiological studies have examined the potential for associations between PFBA exposure and immunosuppression, blood pressure, and renal function, while several experiments in rats and mice have examined potential effects of PFBA exposure on body weight (note: these data were used to inform interpretation of the health effects discussed in prior sections), hematological effects, and ocular effects. Given the paucity of studies available and the lack of consistent or coherent effects of PFBA exposure, there is insufficient evidence to determine whether any of these evaluated outcomes might represent potential human health hazards of PFBA exposure. Additional studies on these health effects could modify these interpretations.

#### Human Studies

Two studies examined the association between PFBA exposure and immunosuppression. One medium confidence (https://hawc.epa.gov/rob/study/101187935/) study examined severity of COVID-19 illness in Denmark using biobank samples and national registry data (Grandjean et al., 2020). There was some concern for selection bias in this study due to the expectation that biobank samples were more likely to be available for individuals with chronic health concerns. In addition, severity of COVID-19 is not a direct measure of immune suppression as other factors may contribute to illness severity. This study reported higher odds of severe disease (based on hospitalization, admission to intensive care and/or death) with higher exposure to PFBA (OR = 1.57, 95% CI = 0.96, 2.58 for >LOD vs. LOD in all participants; OR = 2.10, 95% CI = 1.02, 4.33 in only participants with exposure measured at the time of diagnosis, which reduces concern for selection bias). In addition, one low confidence (https://hawc.epa.gov/rob/study/101187934/) cross-sectional study in China analyzed hepatitis B surface antibody (Zeng et al., 2020). This study was downgraded due to concerns for exposure misclassification resulting from lack of temporality between the exposure and outcome. There is no way to determine when participants were exposed to hepatitis B; additionally, vaccination status was not considered. This study reported an inverse association between PFBA exposure and hepatitis B surface antibody (mean difference = −0.18 log mIU/mL, 95% CI = −0.28, −0.08). Overall, both available studies report findings consistent with immune suppression with greater PFBA exposure. However, there is residual uncertainty in both studies, and, in the absence of additional corroboration (see animal evidence discussion below), they do not support a stronger judgment than concluding that there is inadequate evidence of immunosuppression. In addition, neither study is suitable for dose-response modeling due to dichotomous exposure modeling Grandjean et al. (2020) and study limitations Zeng et al. (2020). In addition, neither study is suitable for dose-response modeling due to dichotomous exposure modeling Grandjean et al. (2020) and study limitations Zeng et al. (2020).

One medium confidence (https://hawcprd.epa.gov/rob/study/100517936/) cross-sectional study examined the association between PFBA exposure and blood pressure and reported statistically significant increased odds of hypertension (OR = 1.10 [95%CI: 1.04−1.17 per ln-PFBA, ng/mL]) and increased systolic blood pressure (β = 0.80 mm HG [95%CI: 0.25−1.34 per ln-PFBA, ng/mL]). This is despite narrow exposure contrast (median 0.16 ng/mL, IQR 0.01−0.54). Although this was a medium confidence study, potential for bias remains; this includes outcome misclassification resulting from the volatility of blood pressure and its measurement at a single time point and the cross-sectional design. In the absence of additional confirmatory epidemiological studies, or other supportive findings (e.g., from animal studies), the results of this observational study alone are interpreted as “insufficient evidence.”

One low confidence (https://hawcprd.epa.gov/rob/study/100517940/) cross-sectional study Wang et al. (2019) examined the association between PFBA exposure and renal function. They reported statistically significant lower estimated glomerular filtration rate (β: −0.5, 95%CI: −0.8, −0.1 [change in GFR (mL/min/1.73 ^m^2) per 1 ln-serum PFAS (ng/mL)]) and higher, though not significant, odds of chronic kidney disease (OR: 1.1, 95%CI: 1.0,1.2). There is potential for reverse causation in this association, however. In essence, as described in Watkins et al. (2013), decreased renal function (as measured by decreased GFR or other measures) could plausibly lead to higher levels of PFAS, including PFBA, in the blood. This hypothesis is supported by data presented by Watkins et al. (2013), although the conclusions are somewhat uncertain because of the use of modeled exposure data as a negative control and the potential for the causal effect to occur in both directions. Consequently, there is considerable uncertainty in interpreting the results of studies of this outcome.

#### Animal Studies

Body-weight changes were evaluated in multiple high and medium confidence short-term and subchronic-duration studies in rats and mice (Butenhoff et al., 2012a; Foreman et al., 2009; Das et al., 2008; van Otterdijk, 2007a, b). In general, no PFBA-related effects on body weight (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-body-weight-effect-size-animal/) were observed in any study. Foreman et al. (2009) reported that body weighs were not affected in any exposure group of Sv/129 mice. Initial and final body weights were statistically significantly lower in humanized PPARα (hPPARα) Sv/129 mice exposed to 350 mg/kg-day PFBA compared to all other groups, but this was explained by random assignment of animals; body weights in this group actually increased slightly during the study, indicating the lower measured body weights were not treatment related. The change in body weight across the duration of the study was not changed at any dose in any group of animals, however, indicating PFBA exposure had no deleterious effect on adult body weight in mice. Maternal, preweaning, and postweaning body weights were not altered by PFBA exposure in CD-1 mice (Das et al., 2008). Adult body weights were not altered in S-D rats exposed to PFBA for either 28 or 90 days (Butenhoff et al., 2012a; van Otterdijk, 2007a, b). PFBA appears not to affect body weight across multiple species, exposure durations, or lifestages.

Some evidence of effects on the hematological system was observed in S-D rats exposed to PFBA. Following 28 days of exposure, no effects other than on prothrombin time (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-hematology-effect-size-animal/) (PT; a measure of clotting potential) were observed (van Otterdijk, 2007a, b). In males, PT was statistically significantly decreased 6% following exposure to 150 mg/kg-day PFBA, whereas in females, statistically significant decreases of 4% and 5% were observed in the 6- and 30-mg/kg-day dose groups, respectively. PT was decreased 4% in the 150-mg/kg-day dose group in females, but the decrease was not statistically significant. Following the recovery period, no statistically significant decreases in PT were found in male rats, but consistent statistically significant 7%−8% decreases in PT were observed in all exposed female dose groups (p < 0.01). Hematological effects were more pronounced following 90-day exposures. In males, red blood cell counts, hemoglobin, and hematocrit (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-hematology-90-days-effect-size-animal/) were decreased 4%, 6%, and 5%, respectively, and red blood cell distribution width (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-hematology-90-days-effect-siPFBAnimal/) was increased 5% following exposure to 30 mg/kg-day PFBA. Although the number of RBCs and the RBC distribution width were observed to return to control values following recovery, hemoglobin and hematocrit remained decreased 5% relative to control. Mean corpuscular hemoglobin and mean corpuscular hemoglobin concentration (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500073/pfba-hematology-90-days-effect-size-animal/) were decreased 2%−3% in female rats exposed to 30 mg/kg-day PFBA. These effects returned to control levels following recovery. Taken as a whole, although some hematological effects were observed in exposed rats, the effect sizes were quite small, they generally returned to control levels following a recovery period, and no consistency of effects across exposure durations or sexes were found.

Immunotoxicity were observed in mice dermally exposed to up to 15% v/v PFBA (Weatherly et al., 2021). Following 28 days of dermal exposure, the frequency of CD4+ and CD8+ T-cells were decreased in the draining lymph nodes, whereas B-cells, dendritic cells, and CD11b+ cell numbers were increased. Cell frequencies were also changed in the ear pinna following dermal exposure: CD45+, CD4 T-cell, CD8 T-cell, NK cell, eosinophils, neutrophils, and dendritic cell numbers were all increased. Relatively fewer changes were noted in the spleen, however, where total cells, B-cells, CD4 T-cells, neutrophils, and CD11b dendritic cells were all decreased. It is not clear that these data relate to the uncertain evidence of potential immunosuppressive effects observed in the two human studies, and thus they do not strengthen that evidence. Further, no oral PFBA toxicity studies that investigated immunotoxicity were available. Overall, this single animal study does not provide evidence supporting a stronger evidence integration judgment and overall, there is inadequate evidence to determine whether PFBA exposure can cause immunological effects in humans.

Ocular effects also were observed in rats exposed to PFBA for 28 or 90 days (van Otterdijk, 2007a, b). In male rats exposed for 28 days, a delayed bilateral pupillary reflex was observed at 150 mg/kg-day. Although examination of neuronal tissue (including the optic nerve) revealed no histopathological effects, ocular histological effects were observed. Outer retinal degeneration, characterized as a loss of 25%−30% of photoreceptors, was observed along with a decrease (20%−35%) in retinal thickness. Ocular effects also were also observed in the 90-day subchronic study: Delays in pupillary dilation were observed at weeks 8 and 12 in rats exposed to 30 mg/kg-day. These delays were reported to be unilateral, not consistent across the treatment period, and low incidence. No ocular histopathological results were observed in the 90-day subchronic study. Thus, although some ocular effects were observed following PFBA exposure, effects across durations were somewhat inconsistent, with greater effects following short-term exposures than in subchronic exposures. This limited the interpretability of the observed effects.

## 3.3 CARCINOGENICITY

No human or animal studies were available to inform the potential for PFBA exposure to cause cancer. Only one study Crebelli et al. (2019) investigated PFBA-induced genotoxicity: No evidence of DNA damage or micronucleus formation was observed in male mice exposed to PFBA via drinking water for 5 weeks. As shown in Table 4-2, EPA’s carcinogenicity conclusion for the closely related PFAS, PFBS, is inadequate information to assess carcinogenic potential. While there is some evidence of carcinogenicity for PFOA and PFOS, the ability to relate the findings for these longer chain PFAS to PFBA is currently too uncertain to influence the carcinogenicity judgment for PFBA.

Overall, there is inadequate information to assess the carcinogenic potential of PFBA exposure.

9 In this review, “statistical significance” indicates a p-value < 0.05, unless otherwise noted.

10 Clicking on the hyperlinked study evaluation determination will take users to the HAWC visualization for that study evaluation review. From there, users can click on individual domains to see the basis for that decision. In the subsequent hazard sections, hyperlinked endpoint names will take users to the HAWC visualization for that endpoint, from which users can click on the endpoint or studies to see the response data from which the visualization is derived.

11 The Butenhoff et al. (2012a) study reported the findings of two unpublished industry reports: a 28-day and 90-day gavage study fully reported in (van Otterdijk, 2007a, b). These industry reports were conducted at the same facility and largely by the same staff but independently of one another and at different times: July 26, 2006, through September 15, 2006, for the 28-day study and April 5, 2007, through August 6, 2007, for the 90-day study. Throughout the Toxicological Review, both (Butenhoff et al., 2012c; Butenhoff et al., 2012a) and the relevant industry report are cited when discussing effects observed in these reports. Although only one study evaluation was performed for this group of citations in HAWC, the overall confidence level of high applies to both the 28-day and 90-day reports.

12 PPARα is a member of the nuclear receptor superfamily that can be activated endogenously by free fatty acid derivatives. PPARα plays a role in lipid homeostasis but is also associated with cell proliferation, oxidative stress, and inflammation (NJDWQI, 2017; Angrish et al., 2016; Mellor et al., 2016; Hall et al., 2012).