# 2 LITERATURE SEARCH AND STUDY EVALUATION RESULTS

## 2.1 LITERATURE SEARCH AND SCREENING RESULTS

As summarized in Section 1.2.1, the assessment used PECO criteria (see Table 3-1, Appendix A) to identify the evidence that addresses the specific aims of the assessment and focuses the literature screening, including study inclusion. In addition to those studies meeting the PECO criteria, studies containing supplemental material potentially relevant to the specific aims of the assessment were tagged during the literature screening process. Although these studies did not meet PECO criteria, they were not excluded. Rather, they were considered for use in addressing the identified key science issues and other major scientific uncertainties identified during assessment development but unanticipated at the time of protocol posting. Studies categorized as “potentially relevant supplemental material” included the following:

- In vivo mechanistic or mode-of-action studies, including non-PECO routes of exposure (e.g., intraperitoneal injection) and non-PECO populations (e.g., nonmammalian models);
- In vitro and in silico models;
- Absorption, distribution, metabolism, and excretion (ADME) and pharmacokinetic (PK) studies (excluding models);
- Exposure assessment or characterization (no health outcome) studies; and
- Human case reports or case-series studies.

The last literature search update prior to release of the draft Toxicological Review for public comment was April 2020. As shown in Figure 2-1, the searches through 2020 yielded 610 unique records, with 4 records identified from additional sources, such as Toxic Substances Control Act (TSCA) submissions, posted National Toxicology Program (NTP) study tables, and review of reference lists from other authoritative sources (ATSDR, 2021). Of the 610 identified, 552 were excluded during title and abstract screening, and 58 were reviewed at the full-text level. Of the 58 screened at the full-text level, 17 were considered to meet the PECO criteria. This included eight epidemiological studies, nine animal studies (including one published study (Butenhoff et al., 2012a) that reported on two unpublished industry reports (van Otterdijk, 2007a) and (van Otterdijk, 2007b), and one in vivo genotoxicity study. No high-throughput screening data on perfluorobutanoic acid (PFBA) were identified from ToxCast or Tox21. Additional literature searches were conducted in April 2021 and 2022. Those studies were screened as described in the protocol, resulting in the identification of two additional studies that met PECO criteria and are included in this revised assessment (Grandjean et al., 2020; Zeng et al., 2020). In addition, a table compiling the published literature submitted in public comments received through the EPA docket (https://www.regulations.gov/docket/EPA-HQ-ORD-2020-0675) was provided to the external peer review panel and posted to the docket. That table includes the full text screening decisions for those studies (ultimately, none of the studies submitted to the docket that were not identified through the literature search updates through 2022 were incorporated into this Toxicological Review).

Figure 2-1 Literature search and screening flow diagram for perfluorobutanoic acid (PFBA)

TheButenhoff et al. (2012a) study reported the findings of two unpublished industry reports: a 28-day and 90-day gavage study fully reported in (van Otterdijk, 2007a, b). All three of these references are listed here as separate studies, but Figure 2-2 below only provides study quality determinations for (Butenhoff et al., 2012a).

## 2.2 STUDY EVALUATION RESULTS

Human and animal studies have evaluated potential effects to the thyroid, reproductive systems, developing fetus, liver, urinary, and other organ systems (e.g., hematological) following exposure to PFBA. The evidence base for these outcomes is presented in Sections 3.2.1–3.2.5.

The evidence base of all repeated-dose oral toxicity studies for PFBA and the related compound ammonium perfluorobutanoate (NH_4_^+^PFB) that are potentially relevant for deriving oral reference dose (RfD) values includes four short-term studies in rats and mice (Permadi et al., 1993; Permadi et al., 1992; Just et al., 1989; Ikeda et al., 1985), two 28-day studies in rats and mice (Butenhoff et al., 2012a; Foreman et al., 2009; van Otterdijk, 2007a), one subchronic-duration study in rats (Butenhoff et al., 2012c; van Otterdijk, 2007b), and one gestational exposure study in mice (Das et al., 2008). In addition, eight epidemiological studies were identified that report on the association between PFBA and human health effects (Nian et al., 2019a; Wang et al., 2019; Song et al., 2018; Bao et al., 2017a; Li et al., 2017a; Li et al., 2017b; Kim et al., 2016; Fu et al., 2014). The available animal studies were generally well conducted (i.e., medium, or high confidence; see Figure 2-2); thus, specific study limitations identified during evaluation are primarily discussed for studies interpreted as low confidence, or when a limitation affects a specific inference for drawing conclusions (e.g., in relation to a specific assessed endpoint within the health effects synthesis sections below). No animal studies were considered uninformative. Thus, all animal studies meeting PECO criteria during literature screening are included in the evidence synthesis and dose-response analysis.

The study evaluations of the available epidemiological studies are summarized in Figure 2-3, and rationales for each domain and overall confidence rating are available in HAWC (see link in Figure 2-3). Based on the study evaluations, one human epidemiological study was considered uninformative due to critical deficiencies in exposure measurement (Kim et al., 2016) this study is not discussed further in this assessment except to point out in more detail its critical deficiencies in the relevant health effects section.

Figure 2-2 Evaluation results for animal studies assessing effects of perfluorobutanoic acid (PFBA; interactive data graphic for rating rationales (https://hawcprd.epa.gov/summary/visual/100500160/))

The following health outcome categories were investigated by the studies listed in Figure 2-2: thyroid effects (Butenhoff et al., 2012a), liver effects (Butenhoff et al., 2012a; Foreman et al., 2009; Das et al., 2008; Permadi et al., 1993; Permadi et al., 1992) developmental effects (Das et al., 2008), and reproductive effects (Butenhoff et al., 2012a).

Figure 2-3 Evaluation results for epidemiological studies assessing effects of perfluorobutanoic acid (PFBA; interactive data graphic for rating rationales (https://hawcprd.epa.gov/summary/visual/100500162/))

The following health outcome categories were investigated by the studies listed in Figure 2-3: thyroid effects (Li et al., 2017b; Kim et al., 2016), liver effects (Nian et al., 2019a), developmental effects (Li et al., 2017a) reproductive effects (Song et al., 2018), blood lipids (Fu et al., 2014) hypertension/blood pressure (Bao et al., 2017b) and renal function (Wang et al., 2019).